# Appendix B. Sample Data Collection Forms

To see the Sample Data Collection Forms, please select the link below. This link will take you to a PDF version of the forms.

Sample Data Collection Forms

## References for Appendix B

1 McAlister F, Ezekowitz J, Wiebe N, Rowe B, Spooner C, Crumley E, et al. Cardiac Resynchronization Therapy for Congestive Heart Failure. Evidence Report/Technology Assessment No. 106 (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-02-0023). AHRQ Publication No. 05-E001-2. Rockville, MD: Agency for Healthcare Research and Quality 2004.
2 Buscemi N, Vandermeer B, Pandya R, Hooton N, Tjosvold L, Hartling L, et al. Melatonin for Treatment of Sleep Disorders. Evidence Report/Technology Assessment No. 108 (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-02-0023). AHRQ Publication No. 05-E001-2. Rockville, MD: Agency for Healthcare Research and Quality. 2004.
3 Schachter H, Reisman J, Tran K, Dales b, Kourad K, Barnes D, et al. Health Effects of Omega-3 Fatty Acids on Asthma. Evidence Report/Technology Assessment No. 91 (Prepared by the University of Ottawa Evidence-based Practice Center under Contract No. 290-02-0021). AHRQ Publication No. 04-E013-2. Rockville, MD: Agency for Healthcare Research and Quality 2004.
4 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Comm Health. 1998;52:377-84.
5 Bonito AJ, Palton LL, Shugars DA, Lohr KN, Nelson MP, Bader JD, et al. Management of dental patients who are HIV-positive. Evidence Report/Technology Assessment No. 37. AHRQ Publication No. 01-E042. Rockville, MD: Agency for Healthcare Research and Quality 2002.
6 Ellis P, Robineson P, Ciliska D, al. e. Diffusion and Dissemination of Evidence-based Cancer Control Interventions. Evidence Report/Technology Assessment Number 79. (Prepared by McMaster University under Contract No. 290-97-0017.) AHRQ Publication No. 03-E033 Rockville, MD: Agency for Healthcare Research and Quality 2003.
7 Oremus M, Hanson M, Whitlock r, Young E, Gupta A, Dal Cin A, et al. - Quality Assessment - Effective Public Health Practice Project Quality Assessment Tool 2003. The Uses of Heparin to Treat Burn Injury: Evidence Report/Technology Assessment No. 148. (Prepared by the McMaster University Evidence-based Practice Center, under Contract No. 290-02-0020). AHRQ Publication No. 07-E004. Rockville, MD: Agency for Healthcare Research and Quality 2006. Appendix E
8 Berkman ND, Bulik CM, Brownley KA, Lohr KN, Sedway JA, Rooks A, et al. Management of eating disorders. Evidence Report/Technology Assessment Number 135. AHRQ Publication No. 06-E010. Rockville, Md: Agency for Healthcare Research and Quality 2006.
9 Viswanathan M, Ammerman A, Eng E, Gartlehner G, Lohr KN, Griffith D, et al. Community-based participatory research: assessing the evidence. Evidence Report/Technology Assessment No. 99. AHRQ Publication No. 04-E022-2. Rockville, MD: Agency for Healthcare Research and Quality 2004.
10 Chou R, Fu R, Carson S, Saha S, Helfand M. Chapter 2: Methods. Empirical Evaluation of the Association Between Methodological Shortcomings and Estimates of Adverse Events: Technical Review No. 13. (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-02-0024.) AHRQ Publication No. 07-0003. Rockville, MD: Agency for Healthcare Research and Quality 2006.
11 Hodge W, Barnes D, Schachter H, Pan Y, Lowcock E, Zhang L, et al. Effects of Omega-3 Fatty Acids on Eye Health. Evidence Report/Technology Assessment No. 117 (Prepared by University of Ottawa Evidence-based Practice Center under Contract No. 290-02-0021.) AHRQ Publication No. 05-E008-2. Rockville, MD: Agency for Healthcare Research and Quality 2005.
12 Viswanathan M, King VJ, Bordley C, Honeycutt AA, Wittenborn J, Jackman AM, et al. Management of bronchiolitis in infants and children. Evidence Report/Technology Assessment Number 69. AHRQ Publication No. 03-E014. Rockville, MD: Agency for Healthcare Research and Quality 2003.
13 Viswanathan M, Hartmann K, McKoy N, Stuart G, Rankins N, Thieda P, et al. Management of Uterine Fibroids: An Update of the Evidence. RTI International-University of North Carolina Evidence-based Practice Center, Contract No. 290-02-0016 2007.
14 Santaguida PL, Balion C, Hunt D, Morrison K, Gerstein H, Raina P, et al. Diagnosis, Prognosis, and Treatment of Impaired Glucose Tolerance and Impaired Fasting Glucose. Evidence Report/Technology Assessment No. 128. (Prepared by the McMaster University Evidence-based Practice Center under Contract No. 290-02-0020). AHRQ Pub No. 05-E026-2. Rockville, MD: Agency for Healthcare Research and Quality 2005.
15 Coulter ID, Hardy ML, Favreau JT, Elfenbaum PD, Morton SC, Roth EA, et al. Structured Abstract. Mind-Body Interventions for Gastrointestinal Conditions: Evidence Report/Technology Assessment No. 40. (Prepared by the Southern California Evidence-based Practice Center/RAND under Contract No. 290-97-0001). AHRQ Publication No. 01-E030. Rockville, MD: Agency for Healthcare Research and Quality 2001.
16 Hardy M, Coulter I, Venuturupalli S, al e. Ayurvedic Interventions for Diabetes Mellitus: A Systematic Review. Evidence Report/Technology Assessment No. 41 (Prepared by Southern California Evidence-based Practice Center/RAND under Contract No. 290-97-0001). AHRQ Publication No. 01-E040 2001.
17 Viswanathan M, Hartmann K, Palmieri R, Lux L, Swinson T, Lohr KN, et al. The use of episiotomy in obstetrical care: a systematic review. Evidence Report/Technology Assessment No. 112. AHRQ Publication No. 05-E009-1. Rockville, MD: Agency for Healthcare Research and Quality 2005.
18 Levine C, Ganz N, Estok R, Stone L, Ludensky V. Systematic Review of the Current Literature Related to Disability and Chronic Fatigue Syndrome. Evidence Report/Technology Assessment No. 66. (Prepared by MetaWorks Inc. Evidence-based Practice Center under Contract No 290-97-0016). AHRQ Publication No. 03-E007. Rockville, MD: Agency for Healthcare Research and Quality 2002.
19 Lau J, Ioannidis J, Balk E, Milch C, Chew P, Terrin N, et al. Evaluation of Technologies for Identifying Acute Cardiac Ischemia in Emergency Departments. Evidence Report/Technology Assessment Number 26. (Prepared by The New England Medical Center Evidence-based Practice Center under Contract No. 290-97-0019) AHRQ Publication No. 01-E006, Rockville, MD: Agency for Healthcare Research and Quality 2001.
20 Gaynes BN, Gavin N, Meltzer-Brody S, Lohr KN, Swinson T, Gartlehner G, et al. Perinatal depression: prevalence, screening accuracy, and screening outcomes. Evidence Report/Technology Assessment No. 119. AHRQ Publication No. 05-E006-2. Rockville, MD: Agency for Healthcare Research and Quality 2005.
21 Kiddoo D, Klassen TP, Lang ME, Friesen C, Russell K, Spooner C, et al. The Effectiveness of Different Methods of Toilet Training for Bowel and Bladder Control. Evidence Report/Technology Assessment No. 147. (Prepared by the University of Alberta Evidence-based Practice Center, under contract number 290-02-0023). AHRQ Publication No. 07-E003. Rockville, MD: Agency for Healthcare Research and Quality 2006.
22 Wilt TJ, Lederle FA, MacDonald R, Jonk YC, Rector TS, Kane RL. . Abdominal Aortic Aneurysm (AAA): Surveillance Article Abstraction Form. Comparison Endovascular and Open Surgical Repairs for Abdominal Aortic Aneurysm: Evidence Report/Technology Assessment No. 144. (Prepared by the University of Minnesota Evidencebased Practice Center under Contract No. 290-02-0009.) AHRQ Publication No. Rockville, MD. Agency for Healthcare Research and Quality 2006:D2–D9. Appendix D
23 Beach J, Rowe BH, Blitz S, Crumley E, Hooton N, Russell K, et al. Diagnosis and Management of Work-Related Asthma. Evidence Report/Technology Assessment No. 129. (Prepared by the University of Alberta Evidence-based Practice Center, under Contract No. 290-02-0023.) AHRQ Publication No. 06-E003-2. Rockville, MD: Agency for Healthcare Research and Quality 2005.
24 Shekelle P, Takata G, Chan L, Mangione-Smith R, Corley PM, Morphew T, et al. Diagnosis, Natural History, and Late Effects of Otitis Media with Effusion. Evidence Report/Technology Assessment No. 55 (Prepared by Southern California Evidence-based Practice Center under Contract No 290-97-0001, Task Order No. 4). AHRQ Publication No. 03-E023. Rockville, MD: Agency for Healthcare Research and Quality 2003.