# Appendix A. Search Strategy

## Focused Search 1: November 2006

#3 | Search “Weight Gain”[MeSH] | 12977
#7 | Search “Pregnancy”[MeSH] OR “Postpartum Period”[MeSH] | 583182
#9 | Search #3 AND #7 | 1939
#10 | Search gestational weight gain | 1694
#11 | Search #9 OR #10 | 3130
#12 | Search #9 OR #10 Limits: English, Humans | 1681
#15 | Search (“Outcome Assessment (Health Care)”[MeSH] OR “Pregnancy Outcome”[MeSH]) OR “Outcome and Process Assessment (Health Care)”[MeSH] Limits: English, Humans | 287919
#16 | Search #12 AND #15 Limits: English, Humans | 297
#17 | Search “Pregnancy Outcome”[MeSH]) Limits: English, Humans | 19056
#18 | Search #12 AND #17 Limits: English, Humans | 255
#19 | Search (“Weight Gain/ethnology”[MeSH] OR “Weight Gain/genetics”[MeSH]) Limits: English, Humans | 97
#20 | Search #12 AND #19 Limits: English, Humans | 21
#22 | Search “Socioeconomic Factors”[MeSH] Limits: English, Humans | 154168
#23 | Search #12 AND #22 Limits: English, Humans | 183
#27 | Search “Body Weight”[MeSH] OR “Body Mass Index”[MeSH] Limits: English, Humans | 125469
#28 | Search #12 AND #27 Limits: English, Humans | 1438
#29 | Search #28 AND #15 Limits: English, Humans | 257
#31 | Search “Obesity”[MeSH] Limits: English, Humans | 49340
#32 | Search “Obesity”[MeSH] Limits: All Adult: 19+ years, English, Female, Humans | 22784
#33 | Search #32 AND #12 Limits: All Adult: 19+ years, English, Female, Humans | 131
#36 | Search #9 OR #10 Limits: English, Publication Date from 1990, Humans | 1453
#38 | Search “United States”[MeSH] Limits: English, Publication Date from 1990, Humans | 364130
#39 | Search #38 AND #36 Limits: English, Publication Date from 1990, Humans | 135
#42 | Search iom | 682
#43 | Search #42 AND #12 | 19
#45 | Search #43 OR #39 Limits: English, Publication Date from 1990, Humans | 150
#47 | Search (“Counseling”[MeSH] OR “Directive Counseling”[MeSH]) Limits: English, Publication Date from 1990, Humans | 11733
#48 | Search #47 AND #12 Limits: English, Publication Date from 1990, Humans | 13
#53 | Search “Body Weights and Measures/instrumentation”[MeSH] Limits: English, Publication Date from 1990, Humans | 13
#54 | Search Body Weights and Measures[MeSH] | 275772
#55 | Search #12 AND #54 | 1030
#66 | Search Anthropometry [mh] | 70445
#67 | Search #55 AND #66 | 350

KQ1: OUTCOMES

#3 | Search “Weight Gain”[MeSH] | 12977
#7 | Search “Pregnancy”[MeSH] OR “Postpartum Period”[MeSH] | 583182
#9 | Search #3 AND #7 | 1939
#10 | Search gestational weight gain | 1694
#11 | Search #9 OR #10 | 3130
#12 | Search #9 OR #10 Limits: English, Humans | 1681
#15 | Search (“Outcome Assessment (Health Care)”[MeSH] OR “Pregnancy Outcome”[MeSH]) OR “Outcome and Process Assessment (Health Care)”[MeSH] Limits: English, Humans | 287919
#16 | Search #12 AND #15 Limits: English, Humans | 297
#17 | Search “Pregnancy Outcome”[MeSH]) Limits: English, Humans | 19056
#18 | Search #12 AND #17 Limits: English, Humans | 255

KQ2: SES

#19 | Search (“Weight Gain/ethnology”[MeSH] OR “Weight Gain/genetics”[MeSH]) Limits: English, Humans | 97
#20 | Search #12 AND #19 Limits: English, Humans | 21
#22 | Search “Socioeconomic Factors”[MeSH] Limits: English, Humans | 154168
#23 | Search #12 AND #22 Limits: English, Humans | 183

KQ3: IOM Guidelines

#27 | Search “Body Weight”[MeSH] OR “Body Mass Index”[MeSH] Limits: English, Humans | 125469
#28 | Search #12 AND #27 Limits: English, Humans | 1438
#29 | Search #28 AND #15 Limits: English, Humans | 257
#31 | Search “Obesity”[MeSH] Limits: English, Humans | 49340
#32 | Search “Obesity”[MeSH] Limits: All Adult: 19+ years, English, Female, Humans | 22784
#33 | Search #32 AND #12 Limits: All Adult: 19+ years, English, Female, Humans | 131
#36 | Search #9 OR #10 Limits: English, Publication Date from 1990, Humans | 1453
#38 | Search “United States”[MeSH] Limits: English, Publication Date from 1990, Humans | 364130
#39 | Search #38 AND #36 Limits: English, Publication Date from 1990, Humans | 135
#42 | Search iom | 682
#43 | Search #42 AND #12 | 19
#45 | Search #43 OR #39 Limits: English, Publication Date from 1990, Humans | 150

KQ4: Recommendations

#47 | Search (“Counseling”[MeSH] OR “Directive Counseling”[MeSH]) Limits: English, Publication Date from 1990, Humans | 11733
#48 | Search #47 AND #12 Limits: English, Publication Date from 1990, Humans | 13

KQ5: Tools

#53 | Search “Body Weights and Measures/instrumentation”[MeSH] Limits: English, Publication Date from 1990, Humans | 13
#54 | Search Body Weights and Measures[MeSH] | 275772
#55 | Search #12 AND #54 | 1030
#66 | Search Anthropometry [mh] | 70445
#67 | Search #55 AND #66 | 350

## Focused Search 2: February 2007

#2 Search “Weight Gain”[MeSH] = 13220

#5 Search pregnancy [mesh] = 577647

#6 Search #2 AND #5 = 1808

#7 Search gestational weight gain = 1725

#8 Search #6 OR #7 = 3023

#9 Search #6 OR #7 Limits: English, Humans =1696

#15 Search (“Outcome Assessment (Health Care)”[MeSH] OR “Outcome and Process Assessment (Health Care)”[MeSH] OR “Pregnancy Outcome”[MeSH]) OR “Reproductive History”[MeSH] OR “birth outcomes” OR “infant health outcomes” OR "maternal health outcomes Limits: English, Humans = 332914

#16 Search #9 AND #15 Limits: English, Humans = 474

#19 Search (“Counseling”[MeSH] OR “Directive Counseling”[MeSH]) = 23091

#20 Search #9 AND #19 = 12

#25 Search “Body Weights and Measures”[MeSH]= 279399

#26 Search #9 AND #25 = 1044

#29 Search “Anthropometry”[MeSH] =71849

#30 Search #26 AND #29 = 359

CINAHL

DE= Weight gain - in pregnancy = 253

63 duplicates

190 new records

COCHRANE = 4 records, already in database

EMBASE = 18 records, 8 new

Total unduplicated database = 913

## Focused Search 3: March 2007

Same search as Focused Search 1 using Cochrane, CINAHL

## Focused Search 4: June 2007

#1 | Search pregnancy | 620141
#2 | Search height OR weight OR BMI OR “body mass index” OR skinfolds OR circumferences OR BIA OR “body impedance analyzer” OR ultrasound OR DEXA OR UWW OR “underwater weighing” OR “BOD POD” OR CT OR MRI | 1369412
#3 | Search #1 AND #2 | 103432
#4 | Search #1 AND #2 Limits: Humans, English | 66133
#5 | Search #1 AND #2 Limits: Publication Date from 1990, Humans, English, All Adult: 19+ years | 24044
#6 | Search BMI OR “body mass index” OR skinfolds OR circumferences OR BIA OR “body impedance analyzer” OR ultrasound OR DEXA OR UWW OR “underwater weighing” OR “BOD POD” OR CT OR MRI Limits: Publication Date from 1990, Humans, English, All Adult: 19+ years | 247723
#7 | Search #5 AND #6 Limits: Publication Date from 1990, Humans, English, All Adult: 19+ years | 15336
#4 | Search (“Pregnancy/physiology”[Majr]) AND (“Weight Gain”[Mesh]) | 379
#7 | Search (“Adipose Tissue/anatomy and histology”[Mesh]) | 14707
#8 | Search #4 AND #7 | 14
#9 | Search (“Pregnancy/physiology”[Majr]) AND (“Weight Gain”[Mesh]) Limits: Publication Date from 1990, Humans, English, All Adult: 19+ years | 148

## Focused Search 5: October 2007

#1 | Search “Weight Gain”[MeSH] AND pregnancy [mesh] | 1889
#2 | Search gestational weight gain | 1812
#3 | Search #1 OR #2 | 3160
#4 | Search #1 OR #2 Limits: added to PubMed in the last 1 year, Humans, English | 98
#5 | Search (“Outcome Assessment (Health Care)”[MeSH] OR “Outcome and Process Assessment (Health Care)”[MeSH] OR “Pregnancy Outcome”[MeSH]) OR “Reproductive History”[MeSH] OR “birth outcomes” OR “infant health outcomes” OR “maternal health outcomes” | 395351
#6 | Search #4 AND #5 | 26
#7 | Search (“Counseling”[MeSH] OR “Directive Counseling”[MeSH]) | 23918
#8 | Search #4 AND #7 | 1
#9 | Search “Body Weights and Measures”[MeSH] AND“Anthropometry”[MeSH] | 42873
#10 | Search #4 AND #9 | 34
#11 | Search (“Pregnancy/physiology”[Majr]) AND (“Weight Gain”[Mesh]) AND (“Adipose Tissue/anatomy and histology”[Mesh]) | 14
#12 | Search (“Pregnancy/physiology”[Majr]) AND (“Weight Gain”[Mesh]) AND (“Adipose Tissue/anatomy and histology”[Mesh]) Limits: added to PubMed in the last 1 year, Humans, English | 0

CINAHL

DE= Weight gain - in pregnancy = 36

Duplicates = 18

new records = 18

COCHRANE = 1 records

EMBASE = 5 records

Duplicates = 1

New records = 4

58 new records

Total unduplicated database = 1024