# References

1 Institute of Medicine. Nutrition during pregnancy. Part I, weight gain. Washington, DC: National Academy Press 1990.
2 Cogswell ME, Serdula MK, Hungerford DW, Yip R. Gestational weight gain among average-weight and overweight women—what is excessive?. Am J Obstet Gynecol. Feb. 1995;172(2 Pt 1):705-12. [pmid: 7856711].
3 Saldana TM, Siega-Riz AM, Adair LS, Suchindran C. The relationship between pregnancy weight gain and glucose tolerance status among black and white women in central North Carolina. Am J Obstet Gynecol. 2006 12;195(6):1629–35.
4 Kiel DW, Dodson EA, Artal R, Boehmer TK, Leet TL. Gestational weight gain and pregnancy outcomes in obese women: how much is enough?. Obstet Gynecol. Oct. 2007;110(4):752-8. [pmid: 17906005].
5 Finkelstein EA, Fiebelkorn IC, Wang G. National medical expenditures attributable to overweight and obesity: how much and who's paying. Health Affairs. 2003;(Web exclusive): W3-219-W3-226.
6 Finkelstein EA, Ruhm CJ, Kosa KM. Economic causes and consequences of obesity. Annual Review of Public Health. Palo Alto, CA: Annual Reviews 2004.
7 Hedley AA, Ogden CL, Johnson CL, Carroll MD, Curtin LR, Flegal KM. Prevalence of overweight and obesity among US children, adolescents, and adults, 1999-2002. J Am Med Assoc. Jun 16. 2004;291(23):2847-50.
8 Ogden CL, Carroll MD, Curtin LR, McDowell MA, Tabak CJ, Flegal KM. Prevalence of overweight and obesity in the United States, 1999-2004. J Am Med Assoc. Apr 5. 2006;295(13):1549-55.
9 Institute of Medicine. Influence of Pregnancy Weight on Maternal and Child Health: Workshop Report Committee on the Impact of Pregnancy Weight on Maternal and Child Health. Washington, DC: National Academy Press 2007.
10 Kramer MS, Morin I, Yang H, Platt RW, Usher R, McNamara H, et al. Why are babies getting bigger? Temporal trends in fetal growth and its determinants. J Pediatr. Oct. 2002;141(4):538-42. [pmid: 12378194].
11 Martin JA, Hamilton BE, Menacker F, Sutton PD, Mathews TJ. Preliminary births for 2004: Infant and maternal health. Health E-stats. Hyattsville, MD: National Center for Health Statistics. Released November 15, 2005.
12 Eastman NJ, Jackson E. Weight relationships in pregnancy. I. The bearing of maternal weight gain and pre-pregnancy weight on birth weight in full term pregnancies. Obstet Gynecol Surv. Nov. 1968;23(11):1003-25. [pmid: 5702412].
13 Abrams B. Prenatal weight gain and postpartum weight retention: a delicate balance. Am J Pub Health. 1993;83(8):1082-4. [pmid: 8342710].
14 Suitor CW. Maternal weight gain: a report of an expert work group PDF Full Text. Rockville, MD: United States Department of Health and Human Services Public Health Service 1997.
15 Schieve LA, Cogswell ME, Scanlon KS. Trends in pregnancy weight gain within and outside ranges recommended by the Institute of Medicine in a WIC population. Matern Child Health J. Jun. 1998;2(2):111-6. [pmid: 10728266].
16 Lederman SA, Paxton A, Heymsfield SB, Wang J, Thornton J, Pierson RN Jr. Body fat and water changes during pregnancy in women with different body weight and weight gain. Obstet Gynecol. Oct. 1997;90(4 Pt 1):483-8. [pmid: 9380301].
17 Carmichael S, Abrams B, Selvin S. The pattern of maternal weight gain in women with good pregnancy outcomes. Am J Public Health. Dec. 1997;87(12):1984-8. [pmid: 9431288].
18 Caulfield LE, Witter FR, Stoltzfus RJ. Determinants of gestational weight gain outside the recommended ranges among black and white women. Obstet Gynecol. May. 1996;87(5 Pt 1):760-6. [pmid: 8677082].
19 Pregnancy-related behaviors among migrant farm workers—four states, 1989-1993. MMWR Morb Mortal Wkly Rep. 1997 Apr 4;46(13):283–6.
20 Hickey CA, McNeal SF, Menefee L, Ivey S. Prenatal weight gain within upper and lower recommended ranges: effect on birth weight of black and white infants. Obstet Gynecol. Oct. 1997;90(4 Pt 1):489-94. [pmid: 9380302].
21 Siega-Riz AM, Hobel CJ. Predictors of poor maternal weight gain from baseline anthropometric, psychosocial, and demographic information in a Hispanic population. J Am Diet Assoc. Nov. 1997;97(11):1264-8. [pmid: 9366864].
22 Siega-Riz AM, Adair LS, Hobel CJ. Institute of Medicine maternal weight gain recommendations and pregnancy outcome in a predominantly Hispanic population. Obstet Gynecol. Oct. 1994;84(4):565-73. [pmid: 8090394].
23 Dietz PM, Callaghan WM, Cogswell ME, Morrow B, Ferre C, Schieve LA. Combined effects of prepregnancy body mass index and weight gain during pregnancy on the risk of preterm delivery. Epidemiology. Mar. 2006;17(2):170-7. [pmid: 16477257].
24 Oken E, Taveras EM, Kleinman KP, Rich-Edwards JW, Gillman MW. Gestational weight gain and child adiposity at age 3 years. Am J Obstet Gynecol. Apr. 2007;196(4):322. e1–8. [pmid: 17403405].
25 Devader SR, Neeley HL, Myles TD, Leet TL. Evaluation of gestational weight gain guidelines for women with normal prepregnancy body mass index. Obstet Gynecol. Oct. 2007;110(4):745-51. [pmid: 17906004].
26 Stotland NE, Haas JS, Brawarsky P, Jackson RA, Fuentes-Afflick E, Escobar GJ. Body mass index, provider advice, and target gestational weight gain. Obstet Gynecol. Mar. 2005;105(3):633-8. [pmid: 15738036].
27 Olson CM, Strawderman MS. Modifiable behavioral factors in a biopsychosocial model predict inadequate and excessive gestational weight gain. J Am Diet Assoc. Jan. 2003;103(1):48-54. [pmid: 12525793].
28 Cogswell ME, Scanlon KS, Fein SB, Schieve LA. Medically advised, mother's personal target, and actual weight gain during pregnancy. Obstet Gynecol. Oct. 1999;94(4):616-22. [pmid: 10511369].
29 Taffel SM, Keppel KG, Jones GK. Medical advice on maternal weight gain and actual weight gain. Results from the 1988 National Maternal and Infant Health Survey. Ann N Y Acad Sci. Mar 15. 1993;678:293-305. [pmid: 8494272].
30 Brawarsky P, Stotland NE, Jackson RA, Fuentes-Afflick E, Escobar GJ, Rubashkin N, et al. Pre-pregnancy and pregnancy-related factors and the risk of excessive or inadequate gestational weight gain. Int J Gynaecol Obstet. Nov. 2005;91(2):125-31. [pmid: 16202415].
31 Hickey CA, Cliver SP, Goldenberg RL, McNeal SF, Hoffman HJ. Relationship of psychosocial status to low prenatal weight gain among nonobese black and white women delivering at term. Obstet Gynecol. Aug. 1995;86(2):177-83. [pmid: 7617346].
32 Hickey CA. Sociocultural and behavioral influences on weight gain during pregnancy. Am J Clin Nutr. May. 2000;71(5 Suppl):1364S-70S. [pmid: 10799414].
33 Walker LO, Kim M. Psychosocial thriving during late pregnancy: relationship to ethnicity, gestational weight gain, and birth weight. J Obstet Gynecol Neonatal Nurs. May–Jun. 2002;31(3):263-74.
34 King JC. Maternal obesity, glucose intolerance, and inflammation in pregnancy. In: Packer L, Sies H, eds. Oxidative Stress and Inflammatory Mechanisms in Obesity, Diabetes, and the Metabolic Syndrome: Taylor & Francis CRC Press 2007:90–106.
35 Berkman N, Viswanathan M. Model Form for the Evaluation of Observational Studies Included in Systematic Literature Reviews. Durham, NC: RTI International 2007.
36 Deeks JJ, Dinnes J, D'Amico R, Sowden AJ, Sakarovitch C, Song F, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7:iii–x. [PMID: 14499048].
37 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52:377-84. [pmid: 9764259].
38 Brunner Huber LR. Validity of self-reported height and weight in women of reproductive age. Matern Child Health J. 2007;11:137-44. [pmid: 17066316].
39 Gillum RF, Sempos CT. Ethnic variation in validity of classification of overweight and obesity using self-reported weight and height in American women and men: the Third National Health and Nutrition Examination Survey. Nutr J. 2005;4:27. [pmid: 16209706].
40 West SL, King V, Carey TS, McKoy JN, Lohr K, Sutton SF, et al. Systems to rate the strength of scientific evidence. Evidence Report, Technology Assessment No. 47. Rockville, Md.: Agency for Healthcare Research and Quality. AHRQ Publication No. 02-E016 2002.
41 Rodriguez A, Bohlin G, Lindmark G. Symptoms across pregnancy in relation to psychosocial and biomedical factors. Acta Obstet Gynecol Scand. Mar. 2001;80(3):213-23. [pmid: 11207486].
42 Tulman L, Morin KH, Fawcett J. Prepregnant weight and weight gain during pregnancy: relationship to functional status, symptoms, and energy. J Obstet Gynecol Neonatal Nurs. Nov–Dec. 1998;27(6):629-34.
43 Madlon-Kay DJ. Striae gravidarum. Folklore and fact. Arch Fam Med. May. 1993;2(5):507-11. [pmid: 8118566].
44 Atwal GS, Manku LK, Griffiths CE, Polson DW. Striae gravidarum in primiparae. Br J Dermatol. Nov. 2006;155(5):965-9. [pmid: 17034526].
45 Marrero JM, Goggin PM, de Caestecker JS, Pearce JM, Maxwell JD. Determinants of pregnancy heartburn. Br J Obstet Gynaecol. Sep. 1992;99(9):731-4. [pmid: 1420011].
46 Vallianatos H, Brennand EA, Raine K, Stephen Q, Petawabano B, Dannenbaum D, et al. Beliefs and practices of First Nation women about weight gain during pregnancy and lactation: implications for women's health. Can J Nurs Res. Mar. 2006;38(1):102-19. [pmid: 16671283].
47 Dodds L, Fell DB, Joseph KS, Allen VM, Butler B. Outcomes of pregnancies complicated by hyperemesis gravidarum. Obstet Gynecol. Feb. 2006;107(2 Pt 1):285-92. [pmid: 16449113].
48 Kieffer EC, Tabaei BP, Carman WJ, Nolan GH, Guzman JR, Herman WH. The influence of maternal weight and glucose tolerance on infant birthweight in Latino mother-infant pairs. Am J Public Health. Dec. 2006;96(12):2201-8. [pmid: 17077395].
49 Brennand EA, Dannenbaum D, Willows ND. Pregnancy outcomes of First Nations women in relation to pregravid weight and pregnancy weight gain. J Obstet Gynaecol Can. Oct. 2005;27(10):936-44. [pmid: 16411008].
50 Seghieri G, De Bellis A, Anichini R, Alviggi L, Franconi F, Breschi MC. Does parity increase insulin resistance during pregnancy?. Diabet Med. Nov. 2005;22(11):1574-80. [pmid: 16241924].
51 Kabiru W, Raynor BD. Obstetric outcomes associated with increase in BMI category during pregnancy. Am J Obstet Gynecol. Sep. 2004;191(3):928-32. [pmid: 15467566].
52 Murakami M, Ohmichi M, Takahashi T, Shibata A, Fukao A, Morisaki N, et al. Prepregnancy body mass index as an important predictor of perinatal outcomes in Japanese. Arch Gynecol Obstet. Apr. 2005;271(4):311-5. [pmid: 15185098].
53 Thorsdottir I, Torfadottir JE, Birgisdottir BE, Geirsson RT. Weight gain in women of normal weight before pregnancy: complications in pregnancy or delivery and birth outcome. Obstet Gynecol. May. 2002;99(5 Pt 1):799-806. [pmid: 11978290].
54 Bianco AT, Smilen SW, Davis Y, Lopez S, Lapinski R, Lockwood CJ. Pregnancy outcome and weight gain recommendations for the morbidly obese woman. Obstet Gynecol. Jan. 1998;91(1):97-102. [pmid: 9464729].
55 Edwards LE, Hellerstedt WL, Alton IR, Story M, Himes JH. Pregnancy complications and birth outcomes in obese and normal-weight women: effects of gestational weight change. Obstet Gynecol. Mar. 1996;87(3):389-94. [pmid: 8598961].
56 Kieffer EC, Carman WJ, Gillespie BW, Nolan GH, Worley SE, Guzman JR. Obesity and gestational diabetes among African-American women and Latinas in Detroit: implications for disparities in women's health. J Am Med Womens Assoc. 2001 Fall;56(4):181–7, 96.
57 Hackmon R, James R, O'Reilly Green C, Ferber A, Barnhard Y, Divon M. The impact of maternal age, body mass index and maternal weight gain on the glucose challenge test in pregnancy. J Matern Fetal Neonatal Med. Mar. 2007;20(3):253-7. [pmid: 17437228].
58 Cedergren M. Effects of gestational weight gain and body mass index on obstetric outcome in Sweden. Int J Gynaecol Obstet. Jun. 2006;93(3):269-74. [pmid: 16626716].
59 Jensen DM, Ovesen P, Beck-Nielsen H, Molsted-Pedersen L, Sorensen B, Vinter C, et al. Gestational weight gain and pregnancy outcomes in 481 obese glucose-tolerant women. Diabet Care. Sep. 2005;28(9):2118-22.
60 Ogunyemi D, Hullett S, Leeper J, Risk A. Prepregnancy body mass index, weight gain during pregnancy, and perinatal outcome in a rural black population. J Matern Fetal Med. Jul–Aug. 1998;7(4):190-3. [pmid: 9730485].
61 Wataba K, Mizutani T, Wasada K, Morine M, Sugiyama T, Suehara N. Impact of prepregnant body mass index and maternal weight gain on the risk of pregnancy complications in Japanese women. Acta Obstet Gynecol Scand. 2006;85(3):269-76. [pmid: 16553173].
62 Ko CW. Risk factors for gallstone-related hospitalization during pregnancy and the postpartum. Am J Gastroenterol. Oct. 2006;101(10):2263-8. [pmid: 17032191].
63 Lindseth G, Bird-Baker MY. Risk factors for cholelithiasis in pregnancy. Res Nurs Health. 2004;27(6):382-91. [pmid: 15514955].
64 Gosselink CA, Ekwo EE, Woolson RF, Moawad A, Long CR. Dietary habits, prepregnancy weight, and weight gain during pregnancy. Risk of pre term rupture of amniotic sac membranes. Acta Obstet Gynecol Scand. Aug. 1992;71(6):425-38. [pmid: 1326841].
65 Nohr EA, Bech BH, Vaeth M, Rasmussen KM, Henriksen TB, Olsen J. Obesity, gestational weight gain and preterm birth: a study within the Danish National Birth Cohort. Paediatr Perinat Epidemiol. Jan. 2007;21(1):5-14. [pmid: 17239174].
66 Lang JM, Lieberman E, Cohen A. A comparison of risk factors for preterm labor and term small-for-gestational-age birth. Epidemiology. Jul. 1996;7(4):369-76. [pmid: 8793362].
67 Graves BW, DeJoy SA, Heath A, Pekow P. Maternal body mass index, delivery route, and induction of labor in a midwifery caseload. J Midwifery Womens Health. Jul–Aug. 2006;51(4):254-9. [pmid: 16814219].
68 Ekblad U, Grenman S. Maternal weight, weight gain during pregnancy and pregnancy outcome. Int J Gynaecol Obstet. Dec. 1992;39(4):277-83. [pmid: 1361460].
69 Purfield P, Morin K. Excessive weight gain in primigravidas with low-risk pregnancy: selected obstetric consequences. J Obstet Gynecol Neonatal Nurs. Jun. 1995;24(5):434-9.
70 Johnson JW, Longmate JA, Frentzen B. Excessive maternal weight and pregnancy outcome. Am J Obstet Gynecol. Aug. 1992;167(2):353-70. discussion 70–2. [pmid: 1497038].
71 Rosenberg TJ, Garbers S, Lipkind H, Chiasson MA. Maternal obesity and diabetes as risk factors for adverse pregnancy outcomes: differences among 4 racial/ethnic groups. Am J Public Health. Sep. 2005;95(9):1545-51. [pmid: 16118366].
72 Joseph KS, Young DC, Dodds L, O'Connell CM, Allen VM, Chandra S, et al. Changes in maternal characteristics and obstetric practice and recent increases in primary cesarean delivery. Obstet Gynecol. Oct. 2003;102(4):791-800. [pmid: 14551010].
73 Chen G, Uryasev S, Young TK. On prediction of the cesarean delivery risk in a large private practice. Am J Obstet Gynecol. Aug. 2004;191(2):616-24. discussion 24–5. [pmid: 15343249].
74 Young TK, Woodmansee B. Factors that are associated with cesarean delivery in a large private practice: the importance of prepregnancy body mass index and weight gain. Am J Obstet Gynecol. Aug. 2002;187(2):312-8. discussion 8–20. [pmid: 12193918].
75 Shepard MJ, Saftlas AF, Leo-Summers L, Bracken MB. Maternal anthropometric factors and risk of primary cesarean delivery. Am J Public Health. Oct. 1998;88(10):1534-8. [pmid: 9772858].
76 Witter FR, Caulfield LE, Stoltzfus RJ. Influence of maternal anthropometric status and birth weight on the risk of cesarean delivery. Obstet Gynecol. Jun. 1995;85(6):947-51. [pmid: 7770265].
77 Jain NJ, Denk CE, Kruse LK, Dandolu V. Maternal obesity: can pregnancy weight gain modify risk of selected adverse pregnancy outcomes?. Am J Perinatol. May. 2007;24(5):291-8. [pmid: 17514601].
78 Sherrard A, Platt RW, Vallerand D, Usher RH, Zhang X, Kramer MS. Maternal anthropometric risk factors for caesarean delivery before or after onset of labour. BJOG. Sep. 2007;114(9):1088-96. [pmid: 17617199].
79 Juhasz G, Gyamfi C, Gyamfi P, Tocce K, Stone JL. Effect of body mass index and excessive weight gain on success of vaginal birth after cesarean delivery. Obstet Gynecol. Oct. 2005;106(4):741-6. [pmid: 16199630].
80 Geary M, McParland P, Johnson H, Stronge J. Shoulder dystocia—is it predictable?. Eur J Obstet Gynecol Reprod Biol. Sep. 1995;62(1):15-8. [pmid: 7493701].
81 Marshall VA. Maternal health practices and complications of term labor. J Nurse-Midwifery. 1991;36(3):168-73. [pmid: 1856762].
82 Carmichael S, Abrams B, Selvin S. The association of pattern of maternal weight gain with length of gestation and risk of spontaneous preterm delivery. Paediatr Perinat Epidemiol. Oct. 1997;11(4):392-406. [pmid: 9373862].
83 Velonakis EG, Maghiorakos P, Tzonou A, Barrat J, Proteau J, Ladopoulos I. The relation of birth weight and gestational age to biological, occupational and socioeconomic factors. Clin Exp Obstet Gynecol. 1997;24(4):232-6. [pmid: 9478328].
84 Siega-Riz AM, Adair LS, Hobel CJ. Maternal underweight status and inadequate rate of weight gain during the third trimester of pregnancy increases the risk of preterm delivery. J Nutr. Jan. 1996;126(1):146-53. [pmid: 8558295].
85 Stotland NE, Caughey AB, Lahiff M, Abrams B. Weight gain and spontaneous preterm birth: the role of race or ethnicity and previous preterm birth. Obstet Gynecol. Dec. 2006;108(6):1448-55. [pmid: 17138779].
86 Schieve LA, Cogswell ME, Scanlon KS. Maternal weight gain and preterm delivery: differential effects by body mass index. Epidemiology. Mar. 1999;10(2):141-7. [pmid: 10069249].
87 Spinillo A, Capuzzo E, Piazzi G, Ferrari A, Morales V, Di Mario M. Risk for spontaneous preterm delivery by combined body mass index and gestational weight gain patterns. Acta Obstet Gynecol Scand. Jan. 1998;77(1):32-6. [pmid: 9492714].
88 Kramer MS, Coates AL, Michoud MC, Dagenais S, Hamilton EF, Papageorgiou A. Maternal anthropometry and idiopathic preterm labor. Obstet Gynecol. Nov. 1995;86(5):744-8. [pmid: 7566841].
89 Wen SW, Goldenberg RL, Cutter GR, Hoffman HJ, Cliver SP. Intrauterine growth retardation and preterm delivery: prenatal risk factors in an indigent population. Am J Obstet Gynecol. Jan. 1990;162(1):213-8. [pmid: 2301495].
90 Paauw JD, Bierling S, Cook CR, Davis AT. Hyperemesis gravidarum and fetal outcome. J Parenter Enteral Nutr. Mar–Apr. 2005;29(2):93-6.
91 Di Cianni G, Miccoli R, Volpe L, Lencioni C, Ghio A, Giovannitti MG, et al. Maternal triglyceride levels and newborn weight in pregnant women with normal glucose tolerance. Diabet Med. Jan. 2005;22(1):21-5. [pmid: 15606686].
92 Guihard-Costa AM, Papiernik E, Kolb S. Maternal predictors of subcutaneous fat in the term newborn. Acta Paediatr. Mar. 2004;93(3):346-9. [pmid: 15124837].
93 Kirchengast S, Hartmann B. Impact of maternal age and maternal somatic characteristics on newborn size. Am J Hum Biol. Mar–Apr. 2003;15(2):220-8. [pmid: 12621610].
94 Shapiro C, Sutija VG, Bush J. Effect of maternal weight gain on infant birth weight. J Perinat Med. 2000;28(6):428-31. [pmid: 11155426].
95 Cherry FF, Sandstead HH, Wickremasinghe AR. Adolescent pregnancy. Weight and zinc supplementation effects. Ann N Y Acad Sci. Mar 15. 1993;678:334-7. [pmid: 8494277].
96 Springer NS, Bischoping K, Sampselle CM, Mayes FL, Petersen BA. Using early weight gain and other nutrition-related risk factors to predict pregnancy outcomes. J Am Diet Assoc. Feb. 1992;92(2):217-9. [pmid: 1737905].
97 Butte NF, Ellis KJ, Wong WW, Hopkinson JM, Smith EO. Composition of gestational weight gain impacts maternal fat retention and infant birth weight. Am J Obstet Gynecol. Nov. 2003;189(5):1423-32. [pmid: 14634581].
98 Brown JE, Murtaugh MA, Jacobs DR Jr, Margellos HC. Variation in newborn size according to pregnancy weight change by trimester. Am J Clin Nutr. Jul. 2002;76(1):205-9. [pmid: 12081836].
99 Zaren B, Cnattingius S, Lindmark G. Fetal growth impairment from smoking—is it influenced by maternal anthropometry?. Acta Obstet Gynecol Scand Suppl. 1997;165:30-4. [pmid: 9219453].
100 Pezzarossa A, Orlandi N, Baggi V, Dazzi D, Ricciarelli E, Coppola F. Effects of maternal weight variations and gestational diabetes mellitus on neonatal birth weight. J Diabetes Complications. Mar–Apr. 1996;10(2):78-83. [pmid: 8777334].
101 Abrams B, Selvin S. Maternal weight gain pattern and birth weight. Obstet Gynecol. Aug. 1995;86(2):163-9. [pmid: 7617344].
102 Hediger ML, Scholl TO, Schall JI, Healey MF, Fischer RL. Changes in maternal upper arm fat stores are predictors of variation in infant birth weight. J Nutr. Jan. 1994;124(1):24-30. [pmid: 8283291].
103 Groff JY, Mullen PD, Mongoven M, Burau K. Prenatal weight gain patterns and infant birthweight associated with maternal smoking. Birth: Issues in Perinatal Care. 1997;24(4):234-9.
104 Luke B, Hediger ML, Scholl TO. Point of diminishing returns: when does gestational weight gain cease benefiting birthweight and begin adding to maternal obesity?. J Maternal-Fetal Med. 1996;5(4):168-73.
105 Muscati SK, Gray-Donald K, Koski KG. Timing of weight gain during pregnancy: promoting fetal growth and minimizing maternal weight retention. Int J Obes Relat Metab Disord. Jun. 1996;20(6):526-32. [pmid: 8782728].
106 Hickey CA, Uauy R, Rodriguez LM, Jennings LW. Maternal weight gain in low-income black and Hispanic women: evaluation by use of weight-for-height near term. Am J Clin Nutr. Nov. 1990;52(5):938-43. [pmid: 2239772].
107 Desjardins E, Hardwick D. How many visits by health professionals are needed to make a difference in low birthweight? A dose-response study of the Toronto Healthiest Babies Possible program. Can J Public Health. Jul–Aug. 1999;90(4):224-8. [pmid: 10489716].
108 Zhou W, Olsen J. Gestational weight gain as a predictor of birth and placenta weight according to pre-pregnancy body mass index. Acta Obstet Gynecol Scand. Apr. 1997;76(4):300-7. [pmid: 9174421].
109 Lasker JN, Coyle B, Li K, Ortynsky M. Assessment of risk factors for low birth weight deliveries. Health Care for Women International. 2005;26(3):262-80. [pmid: 15804697].
110 Hedderson MM, Weiss NS, Sacks DA, Pettitt DJ, Selby JV, Quesenberry CP, et al. Pregnancy weight gain and risk of neonatal complications: macrosomia, hypoglycemia, and hyperbilirubinemia. Obstet Gynecol. Nov. 2006;108(5):1153-61. [pmid: 17077237].
111 Takimoto H, Sugiyama T, Fukuoka H, Kato N, Yoshiike N. Maternal weight gain ranges for optimal fetal growth in Japanese women. Int J Gynaecol Obstet. Mar. 2006;92(3):272-8. [pmid: 16458895].
112 Bergmann RL, Richter R, Bergmann KE, Plagemann A, Brauer M, Dudenhausen JW. Secular trends in neonatal macrosomia in Berlin: influences of potential determinants. Paediatr Perinat Epidemiol. Jul. 2003;17(3):244-9. [pmid: 12839535].
113 Clausen T, Burski TK, Oyen N, Godang K, Bollerslev J, Henriksen T. Maternal anthropometric and metabolic factors in the first half of pregnancy and risk of neonatal macrosomia in term pregnancies. A prospective study. Eur J Endocrinol. Dec. 2005;153(6):887-94. [pmid: 16322395].
114 Steward DK, Moser DK. Intrauterine growth retardation in full-term newborn infants with birth weights greater than 2,500 g. Res Nurs Health. Dec. 2004;27(6):403-12. [pmid: 15514960].
115 Bo S, Menato G, Signorile A, Bardelli C, Lezo A, Gallo ML, et al. Obesity or diabetes: what is worse for the mother and for the baby?. Diabet Metab. Apr. 2003;29(2 Pt 1):175-8.
116 Caulfield LE, Stoltzfus RJ, Witter FR. Implications of the Institute of Medicine weight gain recommendations for preventing adverse pregnancy outcomes in black and white women. Am J Public Health. Aug. 1998;88(8):1168-74. [pmid: 9702142].
117 Shepard MJ, Bakketeig LS, Jacobsen G, O'Connor T, Bracken MB. Maternal body mass, proportional weight gain, and fetal growth in parous women. Paediatr Perinat Epidemiol. Apr. 1996;10(2):207-19. [pmid: 8778693].
118 Parker JD, Abrams B. Prenatal weight gain advice: an examination of the recent prenatal weight gain recommendations of the Institute of Medicine. Obstet Gynecol. May. 1992;79(5 Pt 1):664-9. [pmid: 1565346].
119 Dawes MG, Grudzinskas JG. Repeated measurement of maternal weight during pregnancy. Is this a useful practice?. Br J Obstet Gynaecol. Feb. 1991;98(2):189-94. [pmid: 1805806].
120 Sunehag A, Berne C, Lindmark G, Ewald U. Gestational diabetes-perinatal outcome with a policy of liberal and intensive insulin therapy. Ups J Med Sci. 1991;96(3):185-98. [pmid: 1810078].
121 Kitajima M, Oka S, Yasuhi I, Fukuda M, Rii Y, Ishimaru T. Maternal serum triglyceride at 24–32 weeks' gestation and newborn weight in nondiabetic women with positive diabetic screens. Obstet Gynecol. May. 2001;97(5 Pt 1):776-80. [pmid: 11339933].
122 Kramer MS, Olivier M, McLean FH, Dougherty GE, Willis DM, Usher RH. Determinants of fetal growth and body proportionality. Pediatrics. Jul. 1990;86(1):18-26. [pmid: 2359680].
123 Cnattingius S, Bergstrom R, Lipworth L, Kramer MS. Prepregnancy weight and the risk of adverse pregnancy outcomes. N Eng J Med. 1998;338(3):147-52.
124 Cheng CJ, Bommarito K, Noguchi A, Holcomb W, Leet T. Body mass index change between pregnancies and small for gestational age births. Obstet Gynecol. Aug. 2004;104(2):286-92. [pmid: 15292001].
125 Nixon SA, Avery MD, Savik K. Outcomes of macrosomic infants in a nurse-midwifery service. J Nurse Midwifery. Jul–Aug. 1998;43(4):280-6. [pmid: 9718883].
126 Nohr EA, Bech BH, Davies MJ, Frydenberg M, Henriksen TB, Olsen J. Prepregnancy obesity and fetal death: a study within the Danish National Birth Cohort. Obstet Gynecol. Aug. 2005;106(2):250-9. [pmid: 16055572].
127 Bracero LA, Byrne DW. Optimal maternal weight gain during singleton pregnancy. Gynecol Obstet Invest. 1998;46(1):9-16. [pmid: 9692334].
128 Naeye RL. Maternal body weight and pregnancy outcome. Am J Clin Nutr. Aug. 1990;52(2):273-9. [pmid: 2375293].
129 Stotland NE, Cheng YW, Hopkins LM, Caughey AB. Gestational weight gain and adverse neonatal outcome among term infants. Obstet Gynecol. Sep. 2006;108(3 Pt 1):635-43. [pmid: 16946225].
130 Spector LG, Davies SM, Robison LL, Hilden JM, Roesler M, Ross JA. Birth characteristics, maternal reproductive history, and the risk of infant leukemia: a report from the Children's Oncology Group. Cancer Epidemiol Biomarkers Prev. Jan. 2007;16(1):128-34. [pmid: 17220341].
131 Vohr BR, McGarvey ST, Coll CG. Effects of maternal gestational diabetes and adiposity on neonatal adiposity and blood pressure. Diabet Care. Apr. 1995;18(4):467-75.
132 Sowan NA, Stember ML. Parental risk factors for infant obesity. Am J Matern Child Nurs. 2000;25(5):234-41.
133 Ong KK, Ahmed ML, Emmett PM, Preece MA, Dunger DB. Association between postnatal catch-up growth and obesity in childhood: prospective cohort study. Br Med J. Apr 8. 2000;320(7240):967-71. [pmid: 10753147].
134 Li C, Goran MI, Kaur H, Nollen N, Ahluwalia JS. Developmental trajectories of overweight during childhood: role of early life factors. Obesity (Silver Spring). Mar. 2007;15(3):760-71. [pmid: 17372328].
135 Yuan W, Basso O, Sorensen HT, Olsen J. Maternal prenatal lifestyle factors and infectious disease in early childhood: a follow-up study of hospitalization within a Danish birth cohort. Pediatrics. Feb. 2001;107(2):357-62. [pmid: 11158470].
136 Linne Y, Dye L, Barkeling B, Rossner S. Weight development over time in parous women—the SPAWN study—15 years follow-up. Int J Obes Relat Metab Disord. Dec. 2003;27(12):1516-22. [pmid: 14634683].
137 Harris HE, Ellison GT, Holliday M. Is there an independent association between parity and maternal weight gain?. Ann Hum Biol. Nov–Dec. 1997;24(6):507-19. [pmid: 9395736].
138 Harris HE, Ellison GT, Holliday M, Lucassen E. The impact of pregnancy on the long-term weight gain of primiparous women in England. Int J Obes Relat Metab Disord. Sep. 1997;21(9):747-55. [pmid: 9376886].
139 Hunt SC, Daines MM, Adams TD, Heath EM, Williams RR. Pregnancy weight retention in morbid obesity. Obes Res. Mar. 1995;3(2):121-30. [pmid: 7719958].
140 Parham ES, Astrom MF, King SH. The association of pregnancy weight gain with the mother's postpartum weight. J Am Diet Assoc. Apr. 1990;90(4):550-4. [pmid: 2319075].
141 Walker L, Freeland-Graves JH, Milani T, George G, Hanss-Nuss H, Kim M, et al. Weight and behavioral and psychosocial factors among ethnically diverse, low-income women after childbirth: II. Trends and correlates. Women Health. 2004;40(2):19-34. [pmid: 15778136].
142 Linne Y, Dye L, Barkeling B, Rossner S. Long-term weight development in women: a 15-year follow-up of the effects of pregnancy. Obes Res. Jul. 2004;12(7):1166-78. [pmid: 15292482].
143 Soltani H, Fraser RB. A longitudinal study of maternal anthropometric changes in normal weight, overweight and obese women during pregnancy and postpartum. Br J Nutr. Jul. 2000;84(1):95-101. [pmid: 10961165].
144 Harris HE, Ellison GT, Clement S. Relative importance of heritable characteristics and lifestyle in the development of maternal obesity. J Epidemiol Community Health. Feb. 1999;53(2):66-74. [pmid: 10396466].
145 Ohlin A, Rossner S. Maternal body weight development after pregnancy. Int J Obes. Feb. 1990;14(2):159-73. [pmid: 2341224].
146 Callaway LK, McIntyre HD, O'Callaghan M, Williams GM, Najman JM, Lawlor DA. The association of hypertensive disorders of pregnancy with weight gain over the subsequent 21 years: findings from a prospective cohort study. Am J Epidemiol. Aug 15. 2007;166(4):421-8. [pmid: 17573337].
147 Kaiser LL, Allen L. Position of the American Dietetic Association: nutrition and lifestyle for a healthy pregnancy outcome. J Am Diet Assoc. Oct. 2002;102(10):1479-90. [pmid: 12396171].
148 Hilakivi-Clarke L, Luoto R, Huttunen T, Koskenvuo M. Pregnancy weight gain and premenopausal breast cancer risk. J Reprod Med. Nov. 2005;50(11):811-6. [pmid: 16419626].
149 Stotland NE, Hopkins LM, Caughey AB. Gestational weight gain, macrosomia, and risk of cesarean birth in nondiabetic nulliparas. Obstet Gynecol. Oct. 2004;104(4):671-7. [pmid: 15458884].
150 Kaiser PS, Kirby RS. Obesity as a risk factor for cesarean in a low-risk population. Obstet Gynecol. Jan. 2001;97(1):39-43. [pmid: 11152904].
151 Hickey CA, Cliver SP, McNeal SF, Hoffman HJ, Goldenberg RL. Prenatal weight gain patterns and spontaneous preterm birth among nonobese black and white women. Obstet Gynecol. Jun. 1995;85(6):909-14. [pmid: 7770259].
152 Schieve LA, Cogswell ME, Scanlon KS, Perry G, Ferre C, Blackmore-Prince C, et al. Prepregnancy body mass index and pregnancy weight gain: associations with preterm delivery. The NMIHS Collaborative Study Group. Obstet Gynecol. Aug. 2000;96(2):194-200. [pmid: 10908762].
153 Nielsen JN, O'Brien KO, Witter FR, Chang SC, Mancini J, Nathanson MS, et al. High gestational weight gain does not improve birth weight in a cohort of African American adolescents. Am J Clin Nutr. Jul. 2006;84(1):183-9. [pmid: 16825694].
154 Stevens-Simon C, McAnarney ER. Adolescent pregnancy. Gestational weight gain and maternal and infant outcomes. Am J Dis Child. Nov. 1992;146(11):1359-64. [pmid: 1415078].
155 Hickey CA, Cliver SP, McNeal SF, Hoffman HJ, Goldenberg RL. Prenatal weight gain patterns and birth weight among nonobese black and white women. Obstet Gynecol. Oct. 1996;88(4 Pt 1):490-6. [pmid: 8841205].
156 Hickey CA, Cliver SP, Goldenberg RL, Kohatsu J, Hoffman HJ. Prenatal weight gain, term birth weight, and fetal growth retardation among high-risk multiparous black and white women. Obstet Gynecol. Apr. 1993;81(4):529-35. [pmid: 8459961].
157 May R. Prepregnancy weight, inappropriate gestational weight gain, and smoking: Relationships to birth weight. Am J Hum Biol. May–Jun. 2007;19(3):305-10. [pmid: 17421006].
158 Scholl TO, Hediger ML, Schall JI, Ances IG, Smith WK. Gestational weight gain, pregnancy outcome, and postpartum weight retention. Obstet Gynecol. Sep. 1995;86(3):423-7. [pmid: 7651655].
159 Hellerstedt WL, Himes JH, Story M, Alton IR, Edwards LE. The effects of cigarette smoking and gestational weight change on birth outcomes in obese and normal-weight women. Am J Public Health. Apr. 1997;87(4):591-6. [pmid: 9146437].
160 Schieve LA, Cogswell ME, Scanlon KS. An empiric evaluation of the Institute of Medicine's pregnancy weight gain guidelines by race. Obstet Gynecol. Jun. 1998;91(6):878-84. [pmid: 9610990].
161 Strauss RS, Dietz WH. Low maternal weight gain in the second or third trimester increases the risk for intrauterine growth retardation. J Nutr. May. 1999;129(5):988-93. [pmid: 10222390].
162 Hulsey TC, Neal D, Bondo SC, Hulsey T, Newman R. Maternal prepregnant body mass index and weight gain related to low birth weight in South Carolina. South Med J. Apr. 2005;98(4):411-5. [pmid: 15898514].
163 Prenatal weight gain and birth weight among Oklahoma mothers. J Okla State Med Assoc. 1996 Dec;89(12):435–8.
164 Rode L, Hegaard HK, Kjaergaard H, Moller LF, Tabor A, Ottesen B. Association between maternal weight gain and birth weight. Obstet Gynecol. Jun. 2007;109(6):1309-15. [pmid: 17540802].
165 Kabali C, Werler MM. Pre-pregnant body mass index, weight gain and the risk of delivering large babies among non-diabetic mothers. Int J Gynaecol Obstet. May. 2007;97(2):100-4. [pmid: 17376448].
166 Baker JL, Michaelsen KF, Sorensen TI, Rasmussen KM. High prepregnant body mass index is associated with early termination of full and any breastfeeding in Danish women. Am J Clin Nutr. Aug. 2007;86(2):404-11. [pmid: 17684212].
167 Li R, Jewell S, Grummer-Strawn L. Maternal obesity and breast-feeding practices. Am J Clin Nutr. Apr. 2003;77(4):931-6. [pmid: 12663294].
168 Rasmussen KM, Hilson JA, Kjolhede CL. Obesity as a risk factor for failure to initiate and sustain lactation. Adv Exp Med Biol. 2002;503:217-22. [pmid: 12026023].
169 Hilson JA, Rasmussen KM, Kjolhede CL. Excessive weight gain during pregnancy is associated with earlier termination of breast-feeding among White women. J Nutr. Jan. 2006;136(1):140-6. [pmid: 16365073].
170 Walker LO, Timmerman GM, Sterling BS, Kim M, Dickson P. Do low-income women attain their pre-pregnant weight by the 6th week of postpartum?. Ethn Dis. Winter. 2004;14(1):119-26. [pmid: 15002931].
171 Amorim AR, Rossner S, Neovius M, Lourenco PM, Linne Y. Does excess pregnancy weight gain constitute a major risk for increasing long-term BMI?. Obesity (Silver Spring). May. 2007;15(5):1278-86. [pmid: 17495204].
172 Walker LO. Predictors of weight gain at 6 and 18 months after childbirth: a pilot study. J Obstet Gynecol Neonat Nurs. 1996;25(1):39-48.
173 Keppel KG, Taffel SM. Pregnancy-related weight gain and retention: implications of the 1990 Institute of Medicine guidelines. Am J Pub Health.83(8):1100–3.
174 Rooney BL, Schauberger CW. Excess pregnancy weight gain and long-term obesity: one decade later. Obstet Gynecol. Aug. 2002;100(2):245-52. [pmid: 12151145].
175 Olson CM, Strawderman MS, Hinton PS, Pearson TA. Gestational weight gain and postpartum behaviors associated with weight change from early pregnancy to 1 y postpartum. Int J Obes Relat Metab Disord. Jan. 2003;27(1):117-27. [pmid: 12532163].
176 Rooney BL, Schauberger CW, Mathiason MA. Impact of perinatal weight change on long-term obesity and obesity-related illnesses. Obstet Gynecol. 2005;106(6):1349-56. [pmid: 16319262].
177 Gunderson EP, Abrams B, Selvin S. The relative importance of gestational gain and maternal characteristics associated with the risk of becoming overweight after pregnancy. Int J Obes Relat Metab Disord. Dec. 2000;24(12):1660-8. [pmid: 11126221].
178 Larciprete G, Valensise H, Vasapollo B, Altomare F, Sorge R, Casalino B, et al. Body composition during normal pregnancy: reference ranges. Acta Diabetol. Oct. 2003;40(Suppl 1):S225-32. [pmid: 14618479].
179 Sohlstrom A, Wahlund LO, Forsum E. Total body fat and its distribution during human reproduction as assessed by magnetic resonance imaging. Basic Life Sci. 1993;60:181-4. [pmid: 8110105].
180 Paxton A, Lederman SA, Heymsfield SB, Wang J, Thornton JC, Pierson RN Jr. Anthropometric equations for studying body fat in pregnant women. Am J Clin Nutr. Jan. 1998;67(1):104-10. [pmid: 9440383].
181 Jovanovic-Peterson L, Crues J, Durak E, Peterson CM. Magnetic resonance imaging in pregnancies complicated by gestational diabetes predicts infant birthweight ratio and neonatal morbidity. Am J Perinatol. Nov. 1993;10(6):432-7. [pmid: 8267806].
182 Bartha JL, Marin-Segura P, Gonzalez-Gonzalez NL, Wagner F, Aguilar-Diosdado M, Hervias-Vivancos B. Ultrasound evaluation of visceral fat and metabolic risk factors during early pregnancy. Obesity (Silver Spring). Sep. 2007;15(9):2233-9. [pmid: 17890491].
183 Williamson DF, Madans J, Anda RF, Kleinman JC, Giovino GA, Byers T. Smoking cessation and severity of weight gain in a national cohort. N Engl J Med. Mar 14. 1991;324(11):739-45. [pmid: 1997840].
184 Viswanathan M, Visco AG, Hartmann K, Wechter ME, Gartlehner G, Wu JM, et al. Cesarean delivery on maternal request. Evid Rep Technol Assess (Full Rep). Mar. 2006;(133):1-138. [pmid: 17627329].
185 Carpenter MW, Sady SP, Sady MA, Haydon B, Coustan DR, Thompson PD. Effect of maternal weight gain during pregnancy on exercise performance. J Appl Physiol. Mar. 1990;68(3):1173-6. [pmid: 2341342].
186 Johnston CS, Christopher FS, Kandell LA. Pregnancy weight gain in adolescents and young adults. J Am Coll Nutr. Jun. 1991;10(3):185-9. [pmid: 1894875].
187 Groth S. Are the Institute of Medicine recommendations for gestational weight gain appropriate for adolescents?. J Obstet Gynecol Neonatal Nurs. Jan–Feb. 2007;36(1):21-7.
188 Cedergren MI. Optimal gestational weight gain for body mass index categories. Obstet Gynecol. Oct. 2007;110(4):759-64. [pmid: 17906006].
189 von Elm E, Altman DG, Egger M, Pocock SJ, Gotzsche PC, Vandenbroucke JP. The Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) statement: guidelines for reporting observational studies. J Clin Epidemiol. Apr. 2008;61(4):344-9. [pmid: 18313558].