# Discussion

This chapter discusses our findings for five key questions (KQs) relating to outcomes of gestational weight gain, modifiers and confounders of outcomes of weight gain, outcomes of weight gain within or outside Institute of Medicine (IOM) recommendations, risks and benefits of recommendations, and anthropometric measures of weight gain.

We note in this discussion both the quality of individual studies (good, fair, or poor, as explained in Chapter 2) and the strength of the evidence for each question or subquestion (also described in Chapter 2) and defined below. As noted in Chapter 2, the quality of each study is based on the summary assessment of quality on nine key domains: background, sample selection, specification of exposure, specification of outcome, soundness of information, followup, analysis comparability, analysis of outcome, and interpretation.

The strength of evidence for each outcome incorporates the quality of the studies and the consistency and volume of the evidence. To reiterate, the levels of strength of evidence are as follows:

I Strong: The evidence is from studies of strong design; results are both clinically important and consistent with minor exceptions at most; results are free from serious doubts about generalizability, bias, or flaws in research design. Studies with negative results have sufficiently large samples to have adequate statistical power.
II Moderate: The evidence is from studies of strong design, but some uncertainty remains because of inconsistencies or concern about generalizability, bias, research design flaws, or adequate sample size. Alternatively, the evidence is consistent but derives from studies of weaker design.
III Weak: The evidence is from a limited number of studies of weaker design. Studies with strong design either have not been done or are inconclusive.
IV No evidence: No published literature.

In this first part of this chapter, we discuss chiefly the outcomes with strong or moderate strength of evidence. The tables present outcomes in the order of strength of evidence and then by the outcomes as presented in Chapter 3. We caution that the levels of evidence assigned to the outcomes below reflect associations, not causality, given the preponderance of observational studies in this literature.

For greater synthesis, we first combine our discussion of outcomes for KQ 1 (outcomes of gestational weight gain, broadly defined) and KQ 3 (outcomes of gestational weight defined by IOM cutpoints). We then take up KQ 2 (modifiers and confounders of gestational weight gain), KQ 4 (risks and benefits of gestational weight gain recommendations), and KQ 5 (anthropometrics of weight measurement during pregnancy). When results are described as significant, we mean statistically significant. We conclude the chapter by examining the limitations of this review and the evidence base and then presenting our recommendations for future research.

## Outcomes of Maternal Weight Gain (KQ 1 and KQ 3)

KQ 1 asks about outcomes of gestational weight gain for infants and for mothers; we had specified more than 30 outcomes as being of interest. We present outcomes of gestational weight gain for each of these categories of outcomes, classified in six categories: maternal antepartum outcomes, maternal intrapartum outcomes, birth outcomes, infant outcomes, child outcomes, and short- and long-term maternal outcomes. We focus chiefly on outcomes for which the evidence is either strong or moderate.

KQ 1 also asks what evidence exists to demonstrate causality. Nearly all the studies in this review are observational studies; therefore, generally this evidence base cannot demonstrate a causal link between gestational weight gain and outcomes. Moreover, observational studies that do not control for confounding or possible explanatory factors cannot be used to comment on causality. These research questions thus require the inclusion and assessment of observational studies for making policy decisions, and decisionmakers will need to take into account the limitations of the evidence base.

Our analysis of outcomes related to weight gains in relationship to recommendations of the Institute of Medicine (KQ 3) classified outcomes into six categories as with KQ 1. KQ 3 also asks about the outcomes of weight loss. Weight loss is not considered appropriate during pregnancy for any weight status. Few studies collected or analyzed these data in a manner that allowed compilation and synthesis.

To enable synthesis and help identify gaps in the evidence, we have combined the discussion of the findings for KQ 1 and KQ3, by outcomes. The levels of evidence assigned below account for consistency, directionality, and quality for associations between gestational weight gain and the outcome. The following tables provide a summary assessment of the outcome and its strength of evidence for KQ 1 and KQ3: maternal antepartum outcomes, Table 41; maternal intrapartum outcomes, Table 42; birth outcomes, Table 43; infant outcomes, Table 44; child outcomes, Table 45; and maternal short- and long-term outcomes, Table 46.

Table 41 Strength of evidence: maternal antepartum outcomes of gestational weight gain

Outcome | Source of evidence | Strength of evidence | Number and quality of studies
Maternal discomforts of pregnancy | KQ 1 | Weak | 2 fair^41,42^ and 3 poor studies^43^–^45^
| KQ 3 | No evidence
Hyperemesis | KQ 1 | Weak | 1 poor^47^
| KQ 3 | No evidence
Abnormal glucose metabolism | KQ 1 | Weak | 2 good,^3,48^ 5 fair^52,^,^57,^,^55,^,^56,^,^53,^ 4 poor^49^–^51,54^
| KQ 3 | Weak | 1 good,^3^ 2 fair,^53,55^ 1 poor^54^
Hypertensive disorders | KQ 1 | Weak | 8 fair,^4,^,^25,^,^52,^,^53,^,^55,58^–^60^ 4 poor,^49,^,^51,^,^54,61^
| KQ 3 | Weak | 4 fair,^4,^,^25,^,^53,55^ 1 poor^54^
Gallstones | KQ 1 | Weak | 1 fair, 1 poor^62,63^
| KQ 3 | No evidence

Table 42 Strength of evidence: maternal intrapartum outcomes of gestational weight gain

Outcome | Source of evidence | Strength of Evidence | Number and Quality of Studies
Premature rupture of membranes | KQ 1 | Weak | 2 Fair^64,65^
| KQ 3 | No evidence
Preterm labor | KQ 1 | Weak | 1 Poor^66^
| KQ 3 | No evidence
Postterm pregnancy | KQ 1 | Weak | 1 Fair^58^
| KQ 1 | Weak | 1 Fair^58^
| KQ 3 | No evidence
Induction of labor | KQ 1 | Weak | 2 Fair,^25,67^ 3 Poor^51,^,^59,68^
| KQ 3 | No evidence
Length of labor | KQ 1 | Weak | 2 Fair,^69,70^ 1 Poor^68^
| KQ 3 | No evidence
Mode of delivery | KQ 1 | Moderate for cesarean delivery; Weak for instrumental delivery | 14 Fair,^4,^,^25,^,^52,^,^58,^,^67,69^–^73,75^–^78^ 7 Poor^49,^,^51,^,^54,^,^59,^,^61,^,^68,74^
| KQ 3 | Moderate evidence for increased risk of cesarean for weight gain above IOM recommendations for underweight and normal weight women Weak inconsistent evidence for weight gain above IOM recommendations for obese or morbidly obese women | 8 Fair,^4,^,^25,^,^53,^,^55,^,^77,^,^118,^,^149,150^ 1 Poor^54^
Vaginal birth after cesarean | KQ 1 | Weak | 1 Poor^79^
| KQ 3 | No evidence
Vaginal lacerations | KQ 1 | Weak | 2 Poor^51,68^
| KQ 3 | No evidence
Shoulder dystocia | KQ 1 | Weak | 3 Poor^51,^,^68,80^
| KQ 3 | No evidence
Cephalopelvic disproportion | KQ 1 | Weak | 1 Fair,^25^ 1 Poor^74^
| KQ 3 | No evidence
Complications of labor and delivery | KQ 1 | Weak | 1 Fair,^53^ 1 Poor^81^
| KQ 3 | No evidence

Table 43 Strength of evidence: birth outcomes of gestational weight gain

Outcome | Source of Evidence | Strength of Evidence | Number and Quality of Studies
Preterm birth | KQ 1 | Strong | 2 Good,^84,88^ 7 Fair,^23,^,^65,^,^71,^,^82,^,^85,^,^86,89^ 3 Poor^59,^,^83,87^
| KQ 3 | Strong for association with weight gain below IOM recommendations; Weak inconsistent for association with weight gain above IOM recommendations | 4 Fair^22,^,^85,^,^151,152^
Birthweight | KQ 1 | Strong | 4 Good,^48,^,^98,^,^103,106^ 12 Fair,^55,^,^70,^,^75,^,^92,^,^93,^,^97,99^–^102,^,^104,105^ 9 Poor^54,^,^59,^,^68,^,^83,^,^90,^,^91,94^–^96^
| KQ 3 | Strong for association between low gains and low birthweight Moderate for association between high gains and high birthweight only for underweight and normal-weight women | 1 Good,^153^ 8 Fair,^20,^,^60,^,^104,154^–^158^ 1 Poor^54^
Low birthweight | KQ 1 | Strong | 1 Good,^106^ 9 Fair,^2,^,^4,^,^52,^,^70,^,^71,^,^75,^,^93,^,^107,108^ 3 Poor^54,^,^95,109^
| KQ 3 | Strong for association between low gains and low birthweight for underweight and normal weight mothers; weak for lack of association between low gain and low birthweight for overweight and obese women | 2 Good,^159,160^ 7 Fair,^2,^,^20,^,^55,^,^60,^,^127,^,^154,161^ 3 Poor^54,^,^162,163^
Macrosomia | KQ 1 | Strong | 1 Good,^110^ 9 Fair,^2,^,^4,^,^70,^,^77,^,^93,^,^108,111^–^113^ 2 Poor^49,59^
| KQ 3 | Moderate only for overweight and obese women | 2 Good,^110,160^ 4 Fair,^2,^,^53,^,^55,164^ 1 Poor^165^
Large-for-gestational-age | KQ 1 | Strong | 1 Good,^116^ 8 Fair,^4,^,^58,^,^100,^,^105,^,^115,^,^118,^,^121,122^ 5 Poor^54,^,^59,^,^61,^,^68,120^
| KQ 3 | Strong for association between high gains and LGA infants, and moderate for protective effect of low gains and LGA infants | 2 Good,^116,159^ 5 Fair,^4,^,^25,^,^118,^,^129,154^ 1 Poor^54^
Small-for-gestational-age | KQ 1 | Strong | 1 Good,^116^ 12 Fair,^4,^,^58,^,^89,^,^105,^,^108,^,^111,^,^114,^,^118,^,^119,122^–^124^ 7 Poor^51,^,^54,^,^59,^,^61,^,^66,^,^68,95^
| KQ 3 | Strong for the association between low gains and SGA infants | 3 Good,^116,^,^153,159^ 6 fair,^4,^,^25,^,^55,^,^118,^,^129,154^ 1 Poor^54^
Apgar scores | KQ 1 | Weak | 3 Fair, 1 Poor^58,^,^61,^,^70,125^
| KQ 3 | Weak | 3 Fair^125,^,^129,154^

Table 44 Strength of evidence: infant outcomes of gestational weight gain

Outcome | Source of Evidence | Strength of Evidence | Number and Quality of Studies
Perinatal mortality | KQ 1 | Weak | 2 fair,^126,127^ 1 poor^128^
| KQ 3 | Weak | 1 fair^127^
Neonatal hypoglycemia | KQ 1 | Weak | 1 good,^110^ 1 fair^129^
| KQ 3 | Weak | 1 good,^110^ 1 fair^129^
Neonatal distress | KQ 1 | Weak | 1 fair^58^
| KQ 3 | No evidence
Hyperbilirubinemia | KQ 1 | Weak | 1 good^110^
| KQ 3 | No evidence
Neonatal hospitalization | KQ 1 | Weak | 1 fair^52^
| KQ 3 | Weak | 2 fair^129,154^
Other infant morbidity | KQ 1 | Weak | 2 fair^129,130^
| KQ 3 | No evidence
Infant BMI | KQ 1 | Weak | 2 fair^122,131^
| KQ 3 | No evidence
Other infant growth characteristics | KQ 1 | Weak | 1 good,^98^ 4 fair,^92,^,^93,^,^117,122^ 1 poor^68^
| KQ 3 | No evidence

Table 45 Strength of evidence: child outcomes of gestational weight gain

Outcomes | Source of evidence | Strength of Evidence | Number and Quality of Studies
Childhood weight status | KQ 1 | Weak | 3 fair,^24,^,^133,134^ 1 poor^132^
| KQ 3 | Weak | 1 fair^24^
Childhood hospitalization for infectious diseases | KQ 1 | Weak | 1 fair^135^
| KQ 3 | No evidence

Table 46 Strength of evidence: maternal outcomes of gestational weight gain

Outcomes | Source of Evidence | Strength of Evidence | Number and Quality of Studies
Lactation | KQ 1 | No evidence
| KQ 3 | Breastfeeding initiation: Moderate for gains below guidelines Exclusive breastfeeding duration: Weak Any breastfeeding duration: Weak | 3 fair studies (4 articles), 3 fair^166^–^169^
Fat accrual | KQ 1 | No evidence
| KQ 3 | Weak | 2 fair^16,97^
Short-term weight retention (11 weeks or less) | KQ 1 | Weak | 1 fair^105^
| KQ 3 | Moderate | 4 fair^104,^,^154,^,^158,170^
Intermediate term weight retention (3 months to 3 years) | KQ 1 | Moderate | 1 good,^144^ 3 fair,^141,^,^143,145^ 1 poor^140^
| KQ 3 | Moderate for weight retention for gains within or above guidelines Weak for weight retention for gains below guidelines | 2 fair,^171,^,^172,174^ 2 poor^158,173^
Inter-pregnancy weight retention | KQ 1 | Weak | 3 fair^137^–^139^
| KQ 3 | Weak | 1 good^177^
Long-term weight retention (>3 years) | KQ 1 | Weak | 1 good,^146^ 1 fair (2 articles)^136,142^
| KQ 3 | Moderate | 3 fair,^171,^,^174,176^
Premenopausal breast cancer | KQ 1 | Weak | 1 fair^148^
| KQ 3 | No evidence

Across all 36 outcomes that we examined for KQ 1, only eight outcomes had strong or moderate strength of evidence. Specifically, we found

- no strong or moderate evidence for maternal antepartum outcomes;
- moderate evidence only for cesarean delivery among maternal intrapartum outcomes;
- moderate or strong evidence for several birth outcomes: preterm birth, birthweight, low birthweight, macrosomia, large-for-gestational-age (LGA), and small-for-gestational-age (SGA);
- no strong or moderate evidence for infant outcomes;
- no strong or moderate evidence for child outcomes; and
- moderate evidence for intermediate-term postpartum weight retention among short- and long-term maternal outcomes.

For KQ 3, we found strong or moderate strength of evidence for 11 outcomes: the 8 identified for KQ 1 and moderate evidence for breastfeeding, short-term postpartum weight retention, and long-term postpartum weight retention.

### Maternal Antepartum Outcomes

We examined the literature for five maternal antepartum outcomes (Table 41). For all, evidence was weak.

#### Maternal discomforts of pregnancy

Results from KQ 1. Five studies (2 fair^41,42^ and 3 poor studies^43^–^45^) provided weak evidence on a variety of discomforts of pregnancy: heartburn,^45^ physical symptoms or level of physical energy,^42^ stretch marks,^43,44^ and overall symptoms.^41^ A study on physical symptoms and level of physical energy found no differences for women who gained an excessive amount of weight compared to those who did not, irrespective of BMI group.^42^ A study on overall symptoms found that total weight gain was associated with a higher frequency of symptoms from mid-pregnancy through the 36th week of gestation.^41^ Both studies of development of striae gravidarum^43,44^ and the heartburn study^45^ were rated poor quality, so no conclusions can be drawn about any relationship between gestational weight gain and these outcomes.

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

#### Hyperemesis

Results from KQ 1. One study of poor quality provided weak evidence that total gestational weight gain of < 7 kg is associated with an antepartum admission related to hyperemesis.^47^ This study had a high number of cases with missing values on gestational weight gain (17 percent of the cohort).

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

#### Abnormal glucose metabolism

Results from KQ 1. Eleven studies (2 good,^3,48^ 5 fair,^52,^,^53,55^–^57^ and 4 poor^49^–^51,54^) provided weak evidence on the relationship between weight gain in pregnancy and the development of abnormal glucose metabolism.^3,48^–^57^ Although 11 studies is a sizeable number of articles, the inconsistencies in methodology and definition across them (i.e., lack of standardization) are too substantial to permit clear summation of the research or to warrant any stronger grading than weak. The major shortcoming was inconsistent diagnostic criteria.

Four studies found that greater weight gains in pregnancy were positively associated with abnormal glucose tolerance;^3,^,^51,^,^55,56^ three (2 good, 1 poor) found that women having lower-than-average weight gains had a higher likelihood of gestational diabetes mellitus (GDM),^48,^,^49,53^ and four articles found no significant association.^50,^,^52,^,^54,57^ Family history of diabetes,^50,56^ maternal age,^3,^,^50,56^ parity,^50^ and body mass index (BMI)^3,^,^50,^,^56,57^ were more predictive of abnormal glucose metabolism than gestational weight gain in the research we reviewed.

Results from KQ 3. Four studies (1 good,^3^ 2 fair,^53,55^ and 1 poor^54^) examined the relationship of the IOM guidelines and abnormal glucose metabolism. These studies offered weak evidence of an association largely because all except one used total gestational weight gain as the exposure variable rather than weight gain until the time of diagnosis. Because treating women with GDM includes dietary counseling and efforts to control weight gain, the use of total weight gain as a predictor of GDM is likely to be a biased indicator.

Synthesis of results. Inconsistent diagnostic criteria and biases in the definition of weight gain result in a weak body of evidence from which we cannot draw conclusions about the association between gestational weight gain and GDM.

#### Maternal hypertensive disorders

Results from KQ 1. Twelve studies (2 fair,^4,^,^25,^,^52,^,^53,^,^55,58^–^60^ 4 poor,^49,^,^51,^,^54,61^) provided weak evidence on the association between prenatal weight gain and the development of pregnancy-induced hypertension.^4,^,^25,^,^49,51^–^55,58^–^61^ Of these 12 studies, 10 reported a relationship between increasing weight and the likelihood of pregnancy-induced hypertension;^4,^,^25,^,^49,^,^51,^,^53,^,^55,58^–^61^ 2 found no effect. One potential explanation for the relationship between weight and gestational hypertension, particularly preeclampsia, is that the condition is marked by edema, which often presents as rapidly increasing weight before delivery. Consequently, the association observed in the majority of the studies may represent the disease state itself, rather than any marker of implied causation.

Results from KQ 3. When we examined maternal hypertensive disorders by IOM guidelines, three fair studies (4 articles)^4,^,^25,^,^53,55^ and one poor study^54^ provided weak evidence of an association relating to pregnancy-induced hypertension.

Synthesis of results. In summary, largely because weight gain is a marker of edema, which is a hallmark of preeclampsia, and because of analytical flaws, the available evidence provides only weak evidence of a relationship between gestational weight gain and the development of pregnancy-induced hypertension.

#### Gallstones

Results from KQ 1. Two studies (2 poor^62^ and 1 fair^63^) provided weak evidence suggesting a potential relationship between weight gain and cholelithiasis.

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

### Maternal Intrapartum Outcomes

In all, we examined the literature for 11 maternal and intrapartum outcomes (Table 42). For one of these—cesarean delivery—the evidence was of moderate strength. For all other outcomes, evidence was weak.

#### Premature rupture of membrane

Results from KQ 1. Two fair studies provided weak evidence that low weight gain (< 21 pounds) or low rate of weight gain (< 275 g per week) is associated with a higher risk of premature rupture of membrane for full-term pregnancies and preterm pregnancies.^64,65^ One study provided weak evidence that high weight gain (> 40 pounds) is also associated with a higher risk of premature rupture of membranes of full-term pregnancies.^64^

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

#### Preterm labor

Results from KQ 1. One poor study yielded weak evidence that weight gain below 0.65 to 0.9 pounds per week significantly increased the risk of premature labor.^66^ Compared with the risk for premature labor for women gaining 0.66 to 0.9 pounds per week, the risk was nearly doubled for women gaining 0.41 to 0.65 pounds per week and nearly tripled for women gaining 0.4 pounds per week or less. Weight gain above 0.9 pounds per week had no significant effect on premature labor.

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

#### Postterm pregnancy

Results from KQ 1. One fair study (weak evidence) showed no effect of either low or high gestational weight gain on postterm pregnancy.^58^

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

Induction of labor. Five studies (2 fair,^25,67^ 3 poor^51,^,^59,68^) examined the association of increased gestational weight gain and labor induction^59,^,^67,68^ or failure of labor induction.^25,51^ These studies provided weak evidence of an association between higher risk of labor induction or failure of induction and higher weight gain. We cannot summarize the magnitude of the effect because of differences in the definition of weight gain and in the nature of confounders controlled for in the analyses; however, the association was statistically significant in different pregravid BMI categories. No study controlled for maternal health characteristics that might lead to labor induction.

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

#### Length of labor

Results from KQ 1. Three studies (2 fair,^69,70^ 1 poor^68^) provided weak evidence on the association between gestational weight gain and length of labor; two studies yielded weak evidence that higher weight gain among women of normal weight was associated with longer labor.^68,69^ These studies inconsistently controlled for confounding factors. A single study that controlled for a subset of confounders provided weak evidence that increased weight gain was associated with labor abnormalities.^183^

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

#### Mode of delivery

Results from KQ 1. Of the 21 studies (14 fair,^4,^,^25,^,^52,^,^58,^,^67,69^–^73,75^–^78^ 7 poor^49,^,^51,^,^54,^,^59,^,^61,^,^68,74^) that examined mode of delivery, all but 4 showed some degree of association between higher weight gain and cesarean delivery; the strength of evidence was moderate.^4,^,^25,^,^49,^,^51,^,^52,^,^54,^,^58,^,^59,^,^61,67^–^76^ Only four studies^49,^,^52,^,^54,67^ failed to show any relationship between gestational weight gain and mode of delivery, specifically cesarean delivery.

Ten studies controlled for route of previous delivery. Of these, five controlled for comorbidities that could have been significant confounders for route of delivery; all found an increased risk of cesarean delivery with increased weight gain.^71,^,^72,^,^75,^,^76,78^ The association appeared to be stronger among overweight and obese women. The evidence is limited by variations in the definition of gestational weight gain and in the definition of cesarean delivery and by the failure in many studies to account for previous route of delivery or underlying health risks. As other reviews suggest, indications for cesarean delivery are driven by underlying maternal health risks^184^ that may be associated with pregravid BMI and weight gain.

Of the five studies that examined risks of instrumental delivery,^25,^,^51,^,^58,^,^68,69^ three suggested a higher risk of instrumental delivery with increasing weight.^25,^,^68,69^ This evidence base was graded weak because it is limited by variations in definition of the outcome and lack of control for confounding.

Results from KQ 3. Nine studies (8 fair,^4,^,^25,^,^53,^,^55,^,^118,^,^148,149^ 1 poor^54^) examined the association between gestational weight gain classified by the IOM guidelines and cesarean delivery. These studies yielded moderate evidence for increased risk of cesarean delivery for weight gain above IOM recommendations for underweight and normal-weight women; they offered weak, inconsistent evidence for obese or morbidly obese women.

The various studies showed the following main findings with respect to cesarean delivery: higher risk with weight gains in excess of IOM recommendations across all pregravid weight groups (2 studies);^149,150^ higher risk with weight gain in excess of IOM recommendations among nonobese women as a group (1 study);^118^ higher risk with weight gain above IOM recommendations for normal-weight women (3^25,^,^118,149^ of 5 studies^25,^,^53,^,^55,^,^118,149^); and higher risk with weight gain above IOM recommendations for underweight women (2 studies).^118,149^

Studies on obese or morbidly obese women were inconsistent. Two suggested no higher risk with weight gain above IOM recommendations,^54,55^ one suggested a higher risk,^149^ and a fourth suggested higher risks with weight gain in excess of 25 pounds.^4^ One study examining the interaction between pregravid overweight or obese status and weight gain above IOM recommendations failed to find a significant effect for either primiparous or multiparous women when the interaction term was defined as pregravid overweight or obese status and weight gain of 25–34 pounds.^77^ When the interaction term was redefined as pregravid overweight or obese status and weight gain greater than 25 pounds, the study found a significant effect only for multiparous women.

Synthesis of results. The majority of studies suggested an association between gestational weight gain and cesarean delivery. This association appeared to be stronger for overweight and obese women. When studies examined the risk of cesarean delivery with respect to IOM recommendations, they were relatively more consistent in demonstrating higher risks for weight gain above IOM recommendations for underweight and normal-weight women, but they were inconsistent in demonstrating increased risks of cesarean delivery for weight gain above IOM recommendations for obese and morbidly obese women. Our findings of a higher risk of cesarean for overweight and obese women, coupled with the lack of significance of weight gain above IOM recommendations for obese and morbidly obese women, suggest that underlying health risks (such as increased risks of abnormal glucose tolerance) associated with high pregravid weight are likely confounders in the relationship between gestational weight gain and cesarean delivery.

#### Vaginal birth after cesarean

Results from KQ 1. One poor study provided weak evidence that gestational weight gain of 40 pounds or more increased the risk of vaginal birth after cesarean (VBAC) failure.^79^

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

#### Vaginal lacerations

Results from KQ 1. Two studies, both rated poor quality, provided weak, inconsistent evidence on the effect of weight gain and vaginal lacerations (incidence of third- or fourth-degree vaginal lacerations or the need for repairs).^51,68^

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

#### Shoulder dystocia

Results from KQ 1. Evidence from three poor studies provided weak evidence on the association of gestational weight gain and shoulder dystocia.^51,^,^68,80^ One study suggested a positive association, but the positive predictive value of high weight gain on shoulder dystocia was only 1 percent. A model of shoulder dystocia that included other predictors, such as multiparity and previous heavy baby, had a total positive predictive value of less than 3 percent. Thus, shoulder dystocia is largely an unpredictable outcome.

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

#### Cephalopelvic disproportion

Results from KQ 1. Two studies (1 fair,^25^ 1 poor^74^) provided weak evidence of an association between higher gestational weight gain and cephalopelvic disproportion (CPD) among normal-weight women. Variability in the definition of CPD and the failure to account for underlying maternal health characteristics weaken the reported association. The poor study failed to identify an association between weight gain and CPD at higher pregravid BMI levels.^74^

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

#### Other complications of labor and delivery

Results from KQ 1. Two studies (1 fair,^53^ 1 poor^81^) provided weak, conflicting evidence on labor and delivery complications. One study failed to find statistically significant results; the other reported that weight gain of more than 40 pounds increased the risk for complications by 40 percent.

The degree of impact was difficult to assess because the studies defined the outcome broadly and differently and used different cutpoints to assign weight gain categories. The outcome, complications, was treated as a dichotomous variable, and analyses were not specific to any one intrapartum or neonatal problem; thus, making meaningful clinical recommendations is impossible.

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

### Birth Outcomes

The knowledge base about the association between gestational weight gain and birth outcomes is, on the whole, stronger than the knowledge base for any other set of outcomes. The relative strength of this body of evidence is unsurprising because the IOM committee based its recommendations on optimizing birthweight and fetal growth; the body of research thereafter was focused on testing these outcomes.

Five outcomes—preterm birth, birthweight, low birthweight, and large-for-gestational-age (LGA) and small-for-gestational-age (SGA) birthweights—all have strong bodies of evidence (Table 43). The outcome of macrosomia was graded moderate strength of evidence; Apgar scores had only weak strength of evidence.

#### Preterm birth

Results from KQ 1. Strong evidence from 12 studies (2 good,^84,88^ 7 fair,^23,^,^65,^,^71,^,^82,^,^85,^,^86,89^ 3 poor^59,^,^83,87^) suggested that weight gains at either end of the spectrum result in a higher risk of premature birth. Overall, the majority of studies adjusted for sociodemographic characteristics and risk factors of preterm birth, including maternal age, smoking status, alcohol consumption, race, marital status, socioeconomic status, and education. Not all studies measured maternal history of obstetric complications. These studies displayed little consistency in terms of adjustment for covariates, inclusion/exclusion of different types of preterm births, and the methods used to define and categorize gestational weight gain. Nevertheless, the results collectively suggested that weight gain is associated with length of gestation^82,83^ and that low weight gain^71,82^ and low rate of weight gain^23,^,^65,^,^82,84^–^87,89^ predict preterm birth.

Among the nine studies that categorized gestational weight gain and reported effect estimates,^23,^,^65,^,^71,84^–^89^ eight reported at least one significant association between low gestational weight gain (as defined in the study) and preterm birth.^23,^,^65,^,^71,84^–^87,89^ Of five studies focused on high gestational weight gain (as defined in the study),^23,^,^65,^,^85,^,^86,89^ four reported at least one significant association between gestational weight gain and preterm birth.^23,^,^65,^,^86,89^

Across the eight studies that considered low rate of weight gain,^23,^,^65,84^–^89^ the rates varied below a cutpoint of 0.37 kg per week; nonetheless, seven consistently showed a higher risk of preterm birth with a low rate of weight gain.^23,^,^65,84^–^87,89^ Across the five studies that considered high rate of weight gain,^23,^,^65,^,^85,^,^86,89^ high rates varied above a cutpoint of 0.52 kg per week; four studies consistently showed a higher risk of preterm birth with a high rate of weight gain.^23,^,^65,^,^86,89^

The association between risk of preterm birth and gestational weight gain may differ by maternal pregravid weight status. In three studies that stratified by pregravid BMI status,^23,^,^86,87^ underweight women tended to have higher risks of preterm birth at low rates of weight gain,^23,^,^86,87^ but obese women tended to have higher risks of preterm birth at high rates of weight gain.^23,86^ One study found no association between the risk of preterm birth and gestational weight gain.^85^

Results from KQ 3. Four studies, all of fair quality, reported on the association between rate of gestational weight gain according to the IOM guidelines and preterm birth.^22,^,^85,^,^151,152^ Despite inconsistencies in the definitions of rate of weight gain and the timing of its calculation, the four studies are consistent in showing increased risks of preterm birth for underweight and normal-weight women, thereby providing strong evidence of an association between weight gain below IOM recommendations and preterm birth. Specifically, two studies found that weight gain below IOM recommendations is associated with a higher risk of preterm birth across all pregravid BMI categories;^22,85^ two studies found this effect for normal-weight women and underweight women.^151,152^ Two studies, one including all pregravid weight status,^22^ and another limited to normal-weight and underweight women,^151^ reported an association only for low weight gain during the third trimester and preterm birth.^22,151^

These studies also provided weak, inconsistent evidence of the association between weight gain above IOM recommendations and preterm birth. One study suggested increased risks of preterm birth with high weight gain for normal-weight women^22^ one suggested no increased risk for underweight and normal-weight women, but a protective effect of high weight gain for high BMI women;^152^ and one suggested no increased risks at all.^85^

Synthesis of results. The majority of studies found an effect of low gestational weight gain on preterm birth. High gestational weight gain was less consistently associated with this outcome. The association for low weight gain held whether investigators used total weight gain or rate of weight gain as the relevant exposure of interest; it also held despite differences in confounders that were controlled for across the studies. Evidence also supported a stronger association between low gestational weight gain and preterm birth for underweight women than for any other category of pregravid weight status.

#### Birthweight

Results from KQ 1. Evidence from 25 studies (4 good,^48,^,^98,^,^103,106^ 12 fair,^55,^,^70,^,^75,^,^92,^,^93,^,^97,99^–^102,^,^104,105^ 9 poor^54,^,^59,^,^68,^,^83,^,^90,^,^91,94^–^96^) provided strong evidence that gestational weight gain is associated with infant birthweight. This relationship held true for various measures of gestational weight gain (categorical measures, total weight gain, net weight gain, proportional weight gain, and weight gain by trimester).

Seven studies^48,^,^93,^,^98,101^–^103,105^ reported that birthweight increased between 16.7 g and 22.6 g for every 1-kg increase in gestational weight gain. Two studies^55,104^ reported values by BMI status,^55,104^ suggesting that the effect of increased gestational weight gain on infant birthweight was more pronounced at lower BMI levels.

Three studies examined the effect of weight gain by trimester on infant birthweight.^98,^,^101,105^ They were consistent in demonstrating that weight gain in the third trimester had the least effect. Two studies that used similar definitions of trimester found that a 1-kg increase in gestational weight gain during the first trimester was associated with 18- to 31-g increases in birthweight. By contrast, a 1-kg increase during the second trimester or during the third trimester was associated with, respectively, 26- to 32.8-g and 7- to 17-g increases in infant birthweight.^98,101^

Results from KQ 3. 10 articles from nine databases (1 good,^153^ 8 fair,^20,^,^60,^,^104,154^–^158^ and 1 poor^54^) examined the association between gestational weight gain defined by IOM guidelines and birthweight. Overall, these articles provided strong evidence that weight gain below IOM recommendations is associated with lower birthweights. All the studies found an association between low weight gain and lower birthweight despite various methods of characterizing gestational weight gain (total, rate, or by trimester).

The evidence that higher weight gains were associated with higher birthweights is moderate because of the inconsistency across the studies. All but one study examined this association.^155^ Seven found an association between high weight gains and higher birthweights,^20,^,^54,^,^60,^,^104,^,^153,^,^154,156^ and two found no association;^157,158^ however, the study populations differed by race and pregravid weight status. We found moderate evidence for three findings: infants of black women had significantly higher birthweights (73 to 330 g);^20,^,^60,^,^153,156^ infants of white women with a BMI less than 29 had higher birthweights (~200 g);^156^ and infants of underweight and normal-weight women had higher birthweights with higher weight gains, but this was not true for overweight and obese women.^104,153^

Synthesis of results. We found strong evidence in support of an association between gestational weight gain and birthweight. Low gestational weight gain is associated with lower birthweights across all pregravid weight status groups. High gestational weight gain resulting in higher birthweight appears to be limited to underweight and normal-weight women.

#### Low birthweight (< 2,500 grams)

Results from KQ1. Thirteen studies (1 good,^106^ 9 fair,^2,^,^4,^,^52,^,^70,^,^71,^,^75,^,^93,^,^107,108^ 3 poor^54,^,^95,109^) provided strong evidence that low weight gain increases the risks of low birthweight (LBW).^2,^,^4,^,^52,^,^54,^,^71,^,^93,106^–^109^ Only two fair studies did not find a statistically significant association between total gestational weight gain and LBW, although their point estimates were in the expected direction.^52,107^ Variations in the definition of gestational weight gain and specification of weight increase category make it challenging to infer the magnitude of risk at different levels of gestational weight gain.

Results from KQ 3. Twelve articles from 10 databases articles (2 good,^159,160^ 7 fair,^2,^,^20,^,^55,^,^60,^,^127,^,^154,161^ and 3 poor^54,^,^162,163^) examined the association between weight gain and low birthweight. These studies provided strong, consistent evidence of an association between weight gain below the IOM guidelines and LBW for underweight and normal-weight women. They suggest no association between weight gain below IOM recommendations and LBW for overweight and obese women, but the strength of evidence is weak.^2,55^

Synthesis of results. Overall, we found strong evidence for an association between low gestational weight gain and low birthweight. The evidence appears to be stronger among women who, before pregnancy, had been underweight or of normal weight than among women who had been overweight or obese; this is especially true when gestational weight gain is a categorical variable (low, medium, high). Despite variations in controlling for confounding and the definition of gestational weight gain, studies were consistent in defining low birthweight as < 2,500 g and in their direction of the outcome.

#### Macrosomia

Results from KQ1. Eleven of 12 studies (1 good,^110^ 9 fair,^2,^,^4,^,^70,^,^77,^,^93,^,^108,111^–^113^ 1 poor^59^) provided strong evidence that high gestational weight gain is associated with greater risks of macrosomia.^2,^,^4,^,^59,^,^70,^,^77,^,^93,^,^108,110^–^113^ One poor study did not support the association.^49^ The relationship between high gestational weight gain and macrosomia held despite variations in definition of macrosomia (> 4,500 g^2,^,^108,^,^110,113^ or > 4,000 g^4,^,^59,^,^70,^,^77,^,^93,^,^111,112^). Generally, the highest weight gains were associated with the highest risks of macrosomia.

Results from KQ3. Seven studies examined the association between gestational weight gain categorized according to the IOM and macrosomia defined as either > 4,000 g or > 4,500 g (2 good,^110,160^ 1 poor,^165^ and the remaining fair^2,^,^53,^,^55,164^). These studies yielded moderate evidence of an association between weight gains above the IOM recommendations and macrosomia. The association differed by pregravid weight status and how weight categories above the IOM recommendations were defined. We found a consistent effect of weight gains above IOM recommendations among normal-weight women on macrosomia in five of seven studies.^53,^,^55,^,^110,^,^160,164^ By contrast, no significant effect was seen among underweight women in three of four studies, although the point estimates were elevated suggesting an increased risk of macrosomia with excessive weight gains.^110,^,^164,165^ Among overweight women and obese women, five out of seven studies found an association,^53,^,^55,^,^110,^,^160,165^ one found the association only with very high weight gains well above the IOM recommendations,^2^ and one found no association.^164^

Synthesis of results. Moderate to strong evidence suggests that high weight gains are associated with macrosomia. This evidence has some inconsistencies in the findings attributable to variations in definitions of both macrosomia and gestational weight gain categories. The evidence suggests no effect of high gestational weight gain for underweight women on macrosomia.

#### Size based on gestational age: large for gestational age (LGA)

Results from KQ1. Fourteen studies (1 good,^116^ 8 fair,^4,^,^58,^,^100,^,^105,^,^115,^,^118,^,^121,122^ 5 poor^54,^,^59,^,^61,^,^68,120^) with varying definitions of weight gain and LGA were consistent in demonstrating an association between high gestational weight gain and LGA; we graded the evidence for this association as strong. This association held whether LGA was defined as birthweight greater than the 90th percentile or as birthweight more than two standard deviations above the mean. Whether BMI modifies this relationship is unclear.

Results from KQ3. Eight articles examined gestational weight gain according to IOM guidelines and LGA (2 good,^116,159^ 5 fair,^4,^,^25,^,^118,^,^129,154^ and 1 poor^54^). These studies provided strong evidence that high weight gains are associated with an increased risk of LGA infants. Only one study failed to find an association.^154^ Weight gains below IOM guidelines, by contrast, were protective against LGA in only four studies (moderate evidence).^4,^,^25,^,^129,159^

Synthesis of results. The increased risk of LGA was consistently seen in women with higher absolute weight gains and in women with gains in excess of the IOM recommendations. The body of literature is large and the evidence is strong for this association despite differences in the definition of LGA and factors that were controlled for confounding.

#### Size based on gestational age: small for gestational age (SGA)

Results from KQ1. Twenty publications (1 good,^116^ 12 fair,^4,^,^58,^,^89,^,^105,^,^108,^,^111,^,^114,^,^118,^,^119,122^–^124^ and 7 poor^51,^,^54,^,^59,^,^61,^,^66,^,^68,95^) provided strong evidence that women in the lowest weight gain categories had higher percentages of SGA infants and were at increased risk of delivering an SGA infant, despite differences across studies in the definition of weight gain and SGA. In general, the risk of SGA among women with low weight gain decreased as BMI increased.

Results from KQ3. Ten articles examined the association between weight gain categorized according to the IOM guidelines and SGA (3 good,^116,^,^153,159^ 1 poor,^54^ and the rest fair^4,^,^25,^,^55,^,^118,^,^129,154^) and yielded strong evidence of an association.between SGA and weight gains below IOM guidelines. Only two studies did not find any evidence of an association.^54,154^ Weight gains above the IOM were protective of SGA in four studies^4,^,^25,^,^129,159^ of six, suggesting a moderate degree of evidence; two did not find an effect.^116,153^.

Synthesis of results. Overall, a large body of literature yielded strong evidence for an association between low gestational weight gain and the risk of having an SGA infant. This association is seen whether weight gain is examined in categories or in absolute terms and despite some inconsistencies in what variables were controlled for in the analysis.

#### Apgar scores

Results from KQ 1. Four studies (3 fair,^58,^,^70,125^ 1 poor study^61^) provided weak evidence on the effect of gestational weight gain on Apgar scores. Two studies (1 fair, 1 poor) suggested some association between weight gain and Apgar scores, but the results were not consistent in the direction or trend of effect; the other two did not report any such association.

Results from KQ 3. Three fair studies provided weak evidence on any association between weight gain according to IOM guidelines and Apgar scores.^125,^,^129,154^

Synthesis of results. Together these studies do not provide consistent evidence on the association between gestational weight gain and Apgar scores.

### Infant Outcomes

We reviewed eight infant outcomes and found weak evidence for all outcomes (Table 44).

#### Perinatal mortality

Results from KQ 1. Three studies (2 fair,^126,127^ 1 poor^128^) with samples ranging from 20,000 to 50,000 women provide weak evidence that low gestational weight gain is associated with a higher risk of perinatal mortality or stillbirth.^126^–^128^ The poor study reported that higher BMI is associated with a higher risk of stillbirth, suggesting a nonlinear relationship between weight gain and stillbirth.^128^ No study controlled for maternal health characteristics that might lead to perinatal mortality.

Results from KQ 3. One fair study on overall perinatal mortality reported a significantly higher proportion of perinatal mortality (1.1 percent) among infants of mothers who gained below the IOM recommendations than the infants whose mothers gained within or above the recommendations. This work, however, did no multivariable modeling using the IOM cutpoints, so it yielded only weak evidence.^127^

Synthesis of results. Together, these results provided weak evidence of an association between low gestational weight gain and perinatal mortality.

#### Neonatal hypoglycemia

Results from KQ 1. Two studies (1 good,^110^ 1 fair^129^) suggested that high gestational weight gain (> 18 kg) or a high rate of weight gain (> 0.4 kg/week) is associated with an increased risk of infant hypoglycemia. The two studies only incompletely adjusted for confounding variables, however.

Results from KQ 3. The same two studies found that high gestational weight gain is associated with an increased risk of neonatal hypoglycemia for weight gain above IOM recommendations. They were consistent in demonstrating a lack of association between weight gain below IOM recommendations and neonatal hypoglycemia.

Synthesis of results. Together, these results provided weak evidence of an association between low gestational weight gain and neonatal hypoglycemia

#### Neonatal distress

Results from KQ 1. One fair study provided weak evidence of a lack of association between low weight gain and fetal distress.^58^

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

#### Hyperbilirubinemia

Results from KQ 1. One good study yielded weak evidence that women who gained in the highest bracket of weight gain per week (more than 0.40 kg/week) during pregnancy had a nearly doubled odds ratio of delivering an infant with hyperbilirubinemia when compared with women gaining between 0.22 kg and 0.31 kg per week.^110^

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

Hospitalization. One fair study provided weak evidence that infants of women who gained less than 8.5 kg during their pregnancy were more likely to require hospitalization than infants born to women who gained the reference amount of 8.5 to 12.5 kg during pregnancy.^52^ The study controlled for maternal age, parity, smoking, prepregnancy BMI, and gestational age but not for other maternal health characteristics.

Results from KQ 3. Two fair studies using different measures of weight gain provided weak, inconsistent evidence on neonatal hospitalization. In one, decreased risk of admission to a neonatal intensive care unit (NICU) was significantly associated with weight gain below IOM guidelines but not with weight gains above the IOM guidelines.^129^ In the other study among black adolescents, risk of NICU admission was significantly associated with a slow rate of weight gain (< 0.23 kg/week).^154^

Synthesis of results. Together, these studies provide weak, inconsistent evidence on the relationship between gestational weight gain and neonatal hospitalization.

#### Other infant morbidity

Results from KQ 1. Two fair studies provided weak evidence on other neonatal and infant morbidity outcomes.^129,130^ In one study, weight gain less than 7 kg was significantly associated with neonatal seizure.^129^ In addition, gestational weight gain greater than 18 kg was significantly associated with assisted ventilation, seizure, polycythemia, and meconium aspiration syndrome. Another study found no significant association between infant leukemia and weight gain during pregnancy after adjusting for sex, race, maternal education, and prepregnancy BMI.^130^

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

#### Infant BMI

Results from KQ 1. Two fair studies provide weak, inconsistent evidence on the influence of weight gain on infant BMI.^122,131^ Any possible association may be attenuated, however, when the weight of the infant is removed from total weight gain.

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

#### Other infant growth characteristics

Results from KQ 1. Five of six studies (1 good,^98^ 4 fair,^92,^,^93,^,^117,122^ 1 poor^68^) provided weak evidence that gestational weight gain is associated with various other infant growth characteristics. Gestational weight gain increased birth length, head circumference, acromial circumference, and diameter frontoccipitalis^93^ and crown-heel length and subscapular skinfold thickness.^92^ Proportional weight gain after 25 weeks of gestation increased fetal growth;^117^ higher gestational weight gains were associated with longer symphysis-fundus height.^68^ Weight gained in the first and third trimester, but not the second trimester, was associated with ponderal index.^98^ A fair study on infant body proportionality failed to find any association between gestational weight gain and the outcome.^122^

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

### Child Outcomes

Only two child outcomes were covered by literature included in this review: childhood weight status and childhood hospitalization (Table 45). The strength of evidence is weak for both.

#### Childhood weight status

Results from KQ 1. Four studies (3 fair^24,^,^133,134^ and 1 poor^132^) examined the long-term effect of gestational weight gain on the offspring's weight status, but they differed in definitions of the outcomes and timing of measurements. They provided weak, inconsistent evidence of this possible association: three studies showed no effect for childhood weight status at 14 or 24 months^132,133^ or much later in life;^134^ one reported an increased risk early in infancy;^134^ and one reported an increased risk at 3 years.^24^

Results from KQ 3. One fair study examined weight gain according to the IOM recommendations and childhood weight status.^24^ Children born to women who gained adequately or excessively had higher odds of being in 50th to 84th, 85th to 94th, and 95th or higher BMI percentile categories than did children born to women who gained inadequately.

Synthesis of results. The evidence of an association between gestational weight gain and childhood weight status is weak because of the limited number of studies and variations in definition of gestational weight gain during pregnancy. Additionally, variations in the age at which child outcomes were measured make comparisons across studies challenging. Studies do not adequately address the potentially lessening role of gestational weight gain on childhood weight status as the importance of child's dietary behavior and physical activity rises.

#### Childhood hospitalization for infectious diseases

Results from KQ 1. One fair study examined the effect of gestational weight gain on childhood hospitalization for infectious diseases.^135^ It provided weak evidence of an effect of weight gains greater than 13 kg only among women who had been underweight before pregnancy (BMI < 18).

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

### Short- and Long-term Maternal Outcomes

The literature covered eight maternal outcomes (Table 46). Of these, evidence for both KQ 1 and KQ 3 is moderate for intermediate-term postpartum weight retention. In addition, we found moderate strength of evidence to support the association between weight gain and breastfeeding initiation, short-term postpartum weight retention, and long-term postpartum weight retention. The evidence for every other outcome (breastfeeding duration, fat accrual, interpregnancy weight retention, and premenpausal breast cancer) was weak.

#### Lactation

Results from KQ 1. We found no evidence on the effect of weight gain (total or rate of weight gain as a continuous variable) on lactation that accounted for pregravid weight.

Results from KQ 3. Three fair studies, published in four articles,^166^–^169^ examined the association of weight gain in relation to the IOM guidelines and breastfeeding. Evidence for an association between weight gains below the guidelines and lower likelihood of breastfeeding initiation is moderate.

For duration of exclusive breastfeeding, the studies offered moderate evidence of a shorter duration of exclusive breastfeeding for women with pregravid obese status.^166,^,^168,169^ They offered only weak evidence for associations with weight gain; one reported shorter duration with higher gains^169^ and another reported no association.^185^

Three studies provide moderate evidence that suggests the length of any breastfeeding among obese women.^166,^,^168,169^ The studies provided only weak evidence that gestational weight gain is associated with the duration of any breastfeeding. Two studies reported that gaining weight above the IOM guidelines was associated with shorter duration,^167,169^ but another reported no association after adjustments for confounding by BMI.^166^

Overall, few studies examined the relationship between gestational weight gain and lactation. Comparison across studies is problematic because of the various definitions of breastfeeding. There appears to be a moderate association between pregravid weight status and breastfeeding; obese women appear to have a lower likelihood of initiating and continuing breastfeeding, regardless of weight gain.

#### Maternal fat accrual and retention postpartum

Results from KQ 1. We found no evidence on the effect of gestational weight gain on maternal fat accrual and retention postpartum that accounted for pregravid weight.

Results from KQ 3. Two fair studies examined differences in the amount of fat retained in the postpartum period by categories of IOM weight gain.^16,97^ Both suggested that higher weight gains were associated with more fat accrual postpartum, but the evidence is weak because of the low number of studies, their limited generalizability, and small sample sizes.

#### Short-term (≤ 11 weeks postpartum) postpartum weight retention

Results from KQ1. One fair study provided weak evidence for an association between gestational weight gain and short-term postpartum weight retention (measured at 6 weeks postpartum).^105^

Results from KQ3. Four studies (all fair^104,^,^154,^,^158,170^) provided moderate, consistent evidence that weight gains (defined as total weight gain or rate of weight gain) exceeding IOM guidelines were associated with greater weight retention measured at or before 11 weeks postpartum.

Synthesis of results. Overall, the studies on weight retention measured within 11 weeks postpartum all showed a consistent effect that higher gestational weight gains are associated with higher weight retention.

#### Intermediate-term (3 months up to 3 years postpartum) postpartum weight retention

Results from KQ1. Five studies (1 good,^144^ 3 fair,^141,^,^143,145^ and 1 poor^140^) provide moderate evidence for an association between gestational weight gain and weight retention between 3 months and 3 years postpartum.

Results from KQ3. Six studies (5 fair^158,^,^171,^,^172,^,^174,175^ and 1 poor^173^) examined the association between weight gain categorized according to IOM guidelines and weight retention within 3 years postpartum. They yielded moderate, consistent evidence that women who gained above the IOM recommendations retained more weight than those who gained within them. They provided only weak evidence about any association when weight gains were below IOM guidelines.

Synthesis of results. Overall, the evidence is moderate for an association between high gestational weight gains (despite variations in definitions) and weight retention in the intermediate term. However, the lack of consistent adjustment for covariates, particularly for factors influencing weight development over time such as physical activity and diet, means that this summary assessment must be interpreted cautiously.

#### Long-term (> 3 years postpartum) postpartum weight retention

Results from KQ1. Two studies (1 good^146^ and 1 fair [2 articles]^136,142^) provided weak evidence on the association between gestational weight gain and long-term postpartum weight retention. The one good study found no association for higher weight gains at 21 years after delivery.^146^

Results from KQ3. Three fair studies examined the association between gestational weight gain according to the IOM guidelines and weight retention several years after delivery.^171,^,^174,176^ They yielded moderate, consistent evidence that higher weight gains were associated with weight retention later in life, but the magnitude of weight retained was small.

Synthesis of results. Overall, the evidence is weak to moderate for an association between high gestational weight gains and long-term weight retention. Once again, the lack of consistent adjustment for covariates, particularly on factors influencing weight development over time such as physical activity and diet, make a summary assessment of the influence of gestational weight gain on long-term postpartum weight retention challenging; our results must be interpreted with caution.

#### Interpregnancy weight retention

Results from KQ1. Three studies, all rated fair quality, provide weak evidence for an association between gestational weight gain and interpregnancy weight retention.^137^–^139^ Two studies reported positive associations between gestational weight gain in an index pregnancy and an increase in weight from the beginning of the index pregnancy to the beginning of the following pregnancy.^137,138^ Another study found no evidence for an association between gestational weight gain across multiple pregnancies and the development of morbid obesity;^139^ however, women who became morbidly obese gained significantly more weight during their first pregnancy and retained significantly more weight after their first and second pregnancies than did controls.

Results from KQ3. One good study examined gestational weight gain according to the IOM guidelines and weight retention until the second pregnancy.^177^ The incidence of overweight at the second pregnancy was significantly higher among women who had gained above IOM recommendations in the prior pregnancy than among those who gained within or below IOM recommendations.^177^ The adjusted odds of becoming overweight between baseline and the start of the second pregnancy was nearly threefold for women gaining above recommendations. We rate this evidence as weak due to the limited number of studies conducted.

Synthesis of results. Overall, evidence for an association between gestational weight gain and interpartum weight retention up to the next pregnancy is weak.

#### Premenopausal breast cancer

Results from KQ 1. One fair study provided weak evidence that gestational weight gain and premenopausal breast cancer are not associated.^148^

Results from KQ 3. We found no evidence from studies examining outcomes of weight gain categorized by IOM recommendations.

## KQ 2: Confounders and Effect Modifiers of Outcomes of Maternal Weight Gain

KQ 2 asks about the confounders and effect modifiers relevant for examining any associations between weight gain (overall and patterns) and birth outcomes; it also asks about the extent to which these confounders and effect modifiers themselves contribute to outcomes. As reported in our results and discussion for KQ 1, the types of confounders and effect modifiers vary considerably by the type of outcome being considered. Moreover, as demonstrated in our summary tables for KQ 1, little consistency exists within the body of evidence for each outcome on which confounders are to be included, and even less consistency exists on their definition.

Given the large variations in the overall body of evidence on the confounders and effect modifiers, our discussion on KQ 2 is limited to outcomes with either moderate or strong evidence of association with weight gain (as identified for KQ 1). These are preterm birth, cesarean delivery, birthweight, low birthweight, macrosomia, LGA infants, SGA infants, and intermediate postpartum weight retention (3 months to 3 years).

Because age, race and ethnicity, and pregravid weight status are key considerations in the 1990 IOM weight gain recommendations, we limit our discussion of KQ 2 to the consideration of these three key variables. In addition, we consider the independent effect of parity on health outcomes. All four variables are defined in highly variable fashion across the included studies. The discussion below represents general trends for these variables.

Finally, because KQ 2 asks about the independent association between confounders and effect modifiers, we consider results only from multivariate analyses for confounders and effect modifiers that included weight gain during pregnancy as a predictor of the outcome. Several studies controlled for age, race and ethnicity, pregravid weight status, and parity, but they did not have abstractable results; the summary findings below are therefore a subset of relevant evidence. These studies together provide strong evidence of the independent association of pregravid weight status on outcomes, moderate evidence on the effects of age and parity, and weak evidence, largely because of insufficient data, on the effect of race.

### Age

Several studies controlled for age in multivariate analysis but did not present their results in the published data. In general, the studies that presented findings for age suggested increasing risks for cesarean delivery and preterm birth as age rises. Key highlights of the evidence are presented below; Table 47 offers further details.

Table 47 Age, gestational weight gain, and outcomes

Outcome | Citations Addressing Effect of Age | Effect of Age
Preterm birth | 5^82,^,^83,87^–^89^ of 12^23,^,^59,^,^65,^,^66,^,^71,82^–^89^ | Higher risks of preterm birth with increased age^82^ Among women with prepregnancy weight < 48 kg, higher risk of preterm birth for women < 21 years than for women ≥ 21 years^87^ Higher risks of preterm delivery for women < 17 and > 25 than for 20–25^89^ No significant association between gestational age and age categories (16–19, 20–24, 25–29, 30–34, 35–45)^83^ No significant association between preterm birth and age categories (< 20, 21–35, ≥35 years)^88^
Cesarean delivery | 5^72,^,^73,76^–^78^ of 21^4,^,^25,^,^49,^,^51,^,^52,^,^54,^,^58,^,^59,^,^61,67^–^78^ | Higher risk of primary cesarean for women > 30 years than for women 20–29 years; lower risk for women < 20 years than for women 20–29 years^72^ Increased risk of cesarean delivery with increased age^73,76^ Increased risk of cesarean delivery with age ≥ 30 years compared with 20–24 years for primiparous and multiparous cesarean delivery; no significant association for other age groups^77^ Higher risk of primary cesarean delivery, with or without labor, for women ≥ 35 years than for women 20–34 years; higher risk of repeat cesarean without labor for women ≥ 35 years than for women < 35 years; no increased risk of repeat cesarean with labor for women age ≥ 35 compared with women < 35; lower risk of primary cesarean with labor for women < 20 years than for women 20–34 years^78^
Birthweight | 6^83,^,^93,^,^98,^,^99,^,^101,102^ of 25^48,^,^54,^,^55,^,^59,^,^68,^,^70,^,^75,^,^83,90^–^106^ | Increased birthweight associated with higher age^93,98^ Lower birthweight for women < 25 years than for women 25–29 years, no significant association for age > 29 years^99^ No significant association between birthweight and age^83,^,^101,102^
Low birthweight (specifically < 2,500 g) | 2^107,109^ of 13^2,^,^4,^,^52,^,^54,^,^70,^,^71,^,^75,^,^93,^,^95,106^–^109^ | Higher risk of LBW for women ≥40 than for women 20–29, no significant association for women 30–29 years compared with women 20–29 years^109^ No significant association between LBW and adolescence^107^
Macrosomia | 4^70,^,^77,^,^93,112^ of 12^2,^,^4,^,^49,^,^59,^,^70,^,^77,^,^93,^,^108,110^–^113^ | Increased risk of macrosomia with higher age^93,112^ No significant association by age^70,77^
Large-for-gestational-age (LGA) | 0 of 14^4,^,^54,^,^58,^,^59,^,^61,^,^68,^,^100,^,^105,^,^115,^,^116,^,^118,120^–^122^ | No abstractable data
Small-for-gestational-age (SGA) | 3^66,^,^89,124^ of 20^4,^,^51,^,^54,^,^58,^,^59,^,^61,^,^66,^,^68,^,^89,^,^95,^,^105,^,^108,^,^111,^,^114,^,^116,^,^118,^,^119,122^–^124^ | Higher risks of IUGR for women > 25 than for women 20–25^89^ No significant association between SGA birth and age^66,124^
Intermediate postpartum weight retention (PPWR) | 3^141,^,^144,145^ of 5^140,^,^141,143^–^145^ | Higher PPWR with higher age^141,145^ No significant association between postpartum weight retention and age^144^

IUGR, intrauterine growth retardation; kg, kilogram; LBW, low birthweight; PPWR, postpartum weight retention; SGA, small-for-gestational-age.

- Of five studies of preterm birth,^82,87^–^89^ three (2 fair,^82,89^ 1 poor^87^) suggested higher risks of preterm birth with increased age; two (1 good,^88^ 1 poor^83^) suggested no effect of age.
- Five fair studies on cesarean delivery^72,^,^73,76^–^78^ suggested a higher risk of cesarean delivery with increased age. The risk was generally true for both primary and repeat cesareans,^77,78^ except for repeat labored cesareans, in the only study that examined the association for that particular subgroup.^78^
- Of six studies concerning birthweight,^83,^,^93,^,^98,^,^99,^,^101,102^ three (1 good,^98^ 2 fair^93,99^) suggested that higher ages are associated with increased birthweight; three (2 fair,^101,102^ 1 poor^83^) suggested no effect of age.
- Two studies were available on low birthweight defined as < 2500 g.^107,109^ One fair study reported no effect of mothers' being adolescents,^107^ and one poor study reported a higher risk for women ages 40 years and older than for women ages 20 to 29 years.^109^
- Two fair studies reported no association between age and macrosomia;^70,77^ two fair studies reported an increased risk of macrosomia with increased maternal age.^93,112^
- Three studies were available on SGA.^66,^,^89,124^ One fair study reported higher risks of intrauterine growth retardation (IUGR) for women older than 25 years^89^ than for women 20 to 25 years; the other two (1 fair,^124^ 1 poor^66^) reported no association between age and SGA.
- Of three studies about intermediate weight retention,^141,^,^144,145^ two fair studies reported higher risk with increased age;^141,145^one good study reported no increased risk.^144^

### Race and Ethnicity

Studies from relatively homogenous populations did not examine the effect of race or ethnicity, so the body of evidence on the independent effect of these variables was limited. These studies suggested that black women, in comparison with white women, have higher risks of preterm birth and SGA and lower risks of LGA and macrosomia. Highlights of the evidence are presented below, with details in Table 48.

Table 48 Race and ethnicity, gestational weight gain, and outcomes

Outcome | Citations Addressing Effect of Race and Ethnicity | Effect of Race and Ethnicity
Preterm birth | 2^82,85^ of 12^23,^,^59,^,^65,^,^71,82^–^89^ | Significantly higher risks of preterm birth for blacks compared with whites, significantly lower risks of preterm birth for Asians compared with whites, no differences for Hispanics compared with whites^82,106^ Among blacks, both low and high gain were associated with spontaneous preterm birth, although for high gain the statistical significance was borderline; among Asians, there was a nonstatistically significant inverse association between high gain and spontaneous preterm birth; among whites and Latinas, low gain was associated with a significantly higher risk of preterm birth but not high gain^85^
Cesarean delivery | 1^77^ of 21^4,^,^25,^,^49,^,^51,^,^52,^,^54,^,^58,^,^59,^,^61,67^–^78^ | No significant association between race/ethnicity and primiparous or multiparous cesarean delivery^77^
Birthweight | 3^94,^,^102,106^ of 25^48,^,^54,^,^55,^,^59,^,^68,^,^70,^,^75,^,^83,90^–^106^ | Lower birthweight for infants of black women than for infants of white women; no significant association for Puerto Rican ancestry compared with white ancestry^102^ No effect of race and ethnicity on birthweight^94,106^
LBW | 2^106,109^ of 13^2,^,^4,^,^52,^,^54,^,^70,^,^71,^,^75,^,^93,^,^95,106^–^109^ | LBW babies more likely among black than Hispanic women^106^ LBW babies more likely among black women and Hispanic women than white women^109^
Macrosomia | 2^70,77^ of 12^2,^,^4,^,^49,^,^59,^,^70,^,^77,^,^93,^,^108,110^–^113^ | Lower risk of macrosomia for black women than for white women^70^ Lower risk of macrosomia for foreign-born Asian non-Hispanic women than for native-born white non-Hispanic women; lower risk of macrosomia for Hispanic women, whether native or foreign-born, than for native-born white non-Hispanics; lower risk of macrosomia for Hispanic women, whether native or foreign-born, than for native-born white non-Hispanics; lower risk of macrosomia for native-born black non-Hispanic women than for native-born white non-Hispanic wwomen; no significant associations for foreign-born white or black non-Hispanic women or native-born Asian non-Hispanic women^77^
LGA | 1^116^ of 14^4,^,^54,^,^58,^,^59,^,^61,^,^68,^,^100,^,^105,^,^115,^,^116,^,^118,120^–^122^ | Lower risk of LGA for black women with BMI 19.8–26 or BMI > 26 than white women at the same BMI levels; no significant association for race at BMI < 19.8^116^
SGA | 3^66,^,^114,116^ of 20^4,^,^51,^,^54,^,^58,^,^59,^,^61,^,^66,^,^68,^,^89,^,^95,^,^105,^,^108,^,^111,^,^114,^,^116,^,^118,^,^119,122^–^124^ | Lower risk of SGA for black women with BMI 19.8–26 than white women at the same BMI level; no significant associations for race at BMI < 19.8 or BMI > 26^116^ Higher risk of SGA infants among black women and women of other races than white women^66^ Higher risk of IUGR among black women than white women; lower risk of IUGR among Asian women than white women^114^
Intermediate PPWR | 1^141^ of 5^140,^,^141,143^–^145^ | Risk of weight retention higher for black and Hispanic than white women^141^

BMI, body mass index; IUGR, intra-uterine growth retardation; LBW, low birthweight; LGA, large-for-gestational-age; PPWR, postpartum weight retention; SGA, small-for-gestational-age.

- Two fair studies suggested higher risks of preterm birth for black women than for white women.^82,85^ One study suggested that among blacks, both high weight gain and low weight gain predicted preterm birth, but that among women of other races and ethnicities, low weight gain alone increased the risk of preterm birth.^85^
- One fair study showed no significant association between race or ethnicity and primiparous or multiparous cesarean delivery.^77^
- One fair study reported an effect of race and ethnicity showing lower infant birthweight for black women than white women; it reported no significant association for women of Puerto Rican ancestry.^102^ Two other studies (1 good,^106^ 1 poor^94^) showed no effect of race and ethnicity.
- Two studies (1 good,^166^ 1 poor^109^) reported a higher risk of LBW infants among black women than among white women.^106,109^ One reported a higher risk of LBW babies among Hispanic women than among white women.^109^
- Two fair studies showed a lower risk of macrosomia for black women than for white women;^70,77^ one reported a lower risk for Hispanic women than for white women.^77^
- One good study reported that black women of normal weight were less likely to have LGA babies than white women of normal weight.^116^
- Three studies (1 good,^116^ 1 fair,^114^ 1 poor^66^) showed higher risks for either SGA^66,116^ or IUGR^114^ for black women than for white women; one study showed lower risks for Asian women than white women.^114^
- One study fair reported that black and Hispanic women retained more weight than white women.^141^

### Pregravid Weight or Body Mass Index

Our search strategy required that included studies have controlled for pregravid weight status; as a result, the evidence on pregravid weight status is strongest. These studies generally demonstrated a strong independent effect of pregravid weight status on all but one of the outcomes for which we found moderate or strong evidence (preterm birth, cesarean delivery, birthweight, low birthweight, macrosomia, LGA infants, SGA infants, and intermediate postpartum weight retention [3 months to 3 years]). The exception was postpartum weight retention, for which the studies showed inconsistent results. Key highlights are presented below, with more details in Table 49:

- Seven studies (2 good,^84,88^ and 5 fair^65,^,^71,^,^82,^,^86,89^) reported a higher risk of preterm birth with lower pregravid weight status; one poor study showed no statistically significant relationship between pregravid weight and gestational age.^83^
- Ten fair studies reported showing a higher risk of cesarean delivery with higher pregravid weight status.^52,^,^67,70^–^73,75^–^78^
- Of 12 studies,^48,^,^83,^,^91,^,^93,^,^94,^,^96,98^–^102,105^ nine (2 good,^48,98^ 4 fair,^93,^,^99,^,^101,105^ 3 poor^83,^,^91,96^) demonstrated higher birthweight with higher pregravid weight status; three (2 fair,^100,102^ 1 poor^94^) suggested no association.
- Of eight studies,^2,^,^52,^,^70,^,^71,^,^93,107^–^109^ six (5 fair,^2,^,^52,^,^70,^,^71,93^ 1 poor^109^) reported lower risks of LBW with higher pregravid weight status; two fair studies suggested no association.^107,108^
- Seven (6 fair,^2,^,^70,^,^93,^,^108,^,^112,113^ 1 poor^83^) studies reported a higher risk of macrosomia with higher pregravid weight (overweight or obese compared with normal weight).
- Of four studies,^100,^,^105,^,^121,122^ three fair studies reported a higher risk of LGA with higher pregravid weight status;^100,^,^105,122^ one fair study found no significant association.^121^
- Nine studies reported lower risks of either SGA (5 fair,^89,^,^105,^,^119,^,^123,124^ 1 poor^66^) or IUGR (3 fair studies)^108,^,^114,122^ with higher pregravid weight status.
- Of three studies,^141,^,^144,145^ one fair study suggested a higher risk of postpartum weight retention with higher pregravid weight status;^141^ two (1 good,^144^ 1 fair^145^) showed no association.

Table 49 Pregravid body mass index, gestational weight gain, and outcomes

Outcome | Citations Addressing Effect of Body Mass Index | Effect of Body Mass Index
Preterm birth | 8^65,^,^71,82^–^84,^,^86,^,^88,89^ of 12^23,^,^59,^,^65,^,^71,82^–^89^ | Higher risks of preterm birth with baseline weight lower than reference pregravid weight of 100–149 pounds; no increased risks with higher than reference weight^71^ Lower risks with increased BMI^82^ Higher risks with decreased BMI^86^ Higher risks with BMI less than normal range (< 19.8–26)^84,88^ Higher risks with pregravid weight < 73 kg than with ≥ 85 kg^89^ Higher risks of preterm birth with obesity (pregravid BMI > 30)^65^ No significant association between pregravid weight and gestational age
Cesarean delivery | 10^52,^,^67,70^–^73,75^–^78^ of 21^4,^,^25,^,^49,^,^51,^,^52,^,^54,^,^58,^,^59,^,^61,67^–^78^ | Higher risk of cesarean delivery with higher BMI^70,^,^73,76^ Higher risks of cesarean delivery with higher pregravid weight^75^ Higher risks of primary cesarean with pregravid weight higher than 100–149 pounds; no increased risks with lower than reference weight^71^ Higher risks of unplanned cesarean with obesity than nonobese weight categories^67^ Higher risk of cesarean with pregravid BMI > 25 than with BMI 18.5–25;no increased risk for BMI < 18.5^52^ Higher risk of primary cesarean delivery for pregravid weight ≥ 70 kg than with 60–69 kg; no significant association with other pregravid weights^72^ Higher risks of primiparous cesarean delivery with pregravid overweight and obese status than with normal weight; higher risk of multiparous cesarean delivery with obese status than with normal weight; no significant association for overweight women compared with normal-weight women for multiparous cesarean delivery^77^ Higher risk of primary cesarean, with or without labor, and repeat cesarean, with or without labor, for pregravid overweight or obese status than for normal weight; lower risk of primary cesarean with labor for underweight women than for normal weight women; no significant association between underweight status and either primary cesarean without labor or repeat cesarean with or without labor^78^
Birthweight | 12^48,^,^83,^,^91,^,^93,^,^94,^,^96,98^–^102,105^ of 25^48,^,^54,^,^55,^,^59,^,^68,^,^70,^,^75,^,^83,90^–^106^ | Higher birthweight associated with higher pregravid weight^48,^,^83,^,^91,^,^93,^,^96,^,^98,101^ Birthweight lower for prepregancy weight < 55 kg than for prepregnancy weight 56–66 kg; birthweight higher with prepregnancy weight > 66 kg^99^ Higher birthweight with higher pregravid weight-for-height (using Metropolitan Life Insurance tables)^105^ No significant association between birthweight and obesity^100^ No difference in birthweight by pregravid BMI groups^94^ No significant association between birthweight and low pregravid BMI^102^
LBW | 8^2,^,^52,^,^70,^,^71,^,^93,107^–^109^ of 13^2,^,^4,^,^52,^,^54,^,^70,^,^71,^,^75,^,^93,^,^95,106^–^109^ | Higher risks of LBW with pregravid weight less than 100–149 pounds, significantly decreased risks with higher than reference weight^71^ Higher risk of LBW with pregravid BMI < 18.5 than with BMI 18.5–25; no significant association for BMI > 25^52^ Lower risk of LBW with increasing pregravid weight^2,93^ Lower risk of LBW with increasing BMI^70^ Lower risk of LBW with BMI > 30 than with BMI 25–29, no significant association for women with BMI < 25^109^ No significant association between LBW and BMI for women gaining < 11 kg (no direct comparisons for other weight gain categories)^108^ No significant association between LBW and pregravid underweight status^107^
Macrosomia | 7^2,^,^70,^,^83,^,^93,^,^108,^,^112,113^ of 12^2,^,^4,^,^49,^,^59,^,^70,^,^77,^,^93,^,^108,110^–^113^ | Increased risk of macrosomia with higher pregravid weight^93,112^ Increased risk of macrosomia with pregravid BMI 19.8–26 compared with BMI < 19.8^70^ Higher risk of macrosomia with first trimester BMI > 25 than with < 20; no higher risk with BMI 20–25 compared with BMI < 20^113^ Higher risk of macrosomia with pregravid BMI > 26 than with BMI < 19.8 for women gaining < 11 kg; no higher risk for women with BMI 19.8–26 (no direct comparisons for other weight gain categories)^108^ Higher rates of macrosomia with higher pregravid weight^2^ Higher risk of macrosomia with pregravid overweight or obese status than with normal weight^77^
LGA | 4^100,^,^105,^,^121,122^ of 14^4,^,^54,^,^58,^,^59,^,^61,^,^68,^,^100,^,^105,^,^115,^,^116,^,^118,120^–^122^ | Higher rates of LGA with higher pregravid BMI^100^ Higher rates of LGA with higher pregravid weight-for-height (using Metropolitan Life Insurance tables)^105^ Lower risk of LGA with lower prepregnancy weight^122^ No significant association between pregravid BMI (per 1 kg/meter^2^ ncrement) and LGA^121^
SGA | 9^66,^,^89,^,^105,^,^108,^,^114,^,^119,122^–^124^ of 20^4,^,^51,^,^54,^,^58,^,^59,^,^61,^,^66,^,^68,^,^89,^,^95,^,^105,^,^108,^,^111,^,^114,^,^116,^,^118,^,^119,122^–^124^ | Higher risks of SGA with pregravid weight < 73 kg than with ≥ 85 kg^89^ Higher risk of growth retardation with BMI < 19.8 than with BMI 19.8–26 for women gaining < 11 kg; no significantly increased risk of growth retardation with BMI > 26 compared with BMI < 19.8 for women gaining < 11 kg (no direct comparisons for other weight gain categories)^108^ Lower risk of SGA with higher pregravid weight-for-height (using Metropolitan Life Insurance tables)^105^ Lower risk of SGA with pregravid BMI higher than 19.9 compared with BMI ≤ 19.9^123^ Higher risk of SGA with pregravid BMI < 20 than with BMI ≥ 20^119^ Higher risks of SGA with pregravid weight < 100 pounds than with pregravid weight 126–160 pounds, lower risk of SGA with pregravid weight 160 pounds than with pregravid weight 126–160 pounds^66^ Higher risks of SGA with pregravid underweight status than with normal weight; lower risks of SGA wth pregravid overweight or obese status than with normal weight^124^ Higher risk of IUGR with lower prepregnancy weight^122^ Lower risk of IUGR with higher pregravid weight^114^
PPWR | 3^141,^,^144,145^ of 5^140,^,^141,143^–^145^ | Increased risk of PPWR with higher pregravid weight^141,^,^144,145^ No significant association between pregravid weight and PPWR^144,145^

BMI, body mass index; IUGR, intra-uterine growth retardation; kg, kilogram; LBW, low birthweight; PPWR, postpartum weight retention; SGA, small for gestational age.

### Parity

Studies did not always examine or report on the independent effect of parity on health outcomes, but the few that did showed consistent effects of increased risks of cesarean delivery and SGA with nulliparity and reduced risks of weight retention for primiparous women. Multiparous women have larger (heavier) babies, lower risks of low birthweight babies, and higher risks of LGA or macrosomia. Key highlights are presented below, with more details in Table 50:

- Five (1 good,^88^ 2 fair,^82,89^ 2 poor^83,87^) studies suggested no association between parity and preterm birth.
- Four fair studies suggested higher risks of cesarean delivery with nulliparity.^67,^,^70,^,^72,76^
- Eight (2 good,^48,98^ 5 fair,^70,^,^92,^,^101,^,^102,105^ 1 poor^83^) studies reported a higher birthweight with higher parity.
- Two studies (1 fair,^70^ 1 poor^109^) reported lower risks of low birthweight with higher parity.
- Three fair studies suggested a higher risk of macrosomia with higher parity.^70,^,^77,112^
- Two of three studies (1 good,^116^ 1 fair^122^) suggested a higher risk of LGA with higher parity;^116,122^one fair study suggested no association between LGA and parity.^115^
- Three studies (1 good,^116^ 1 fair,^89^ 1 poor^66^) suggested greater risks of SGA^66,116^ or IUGR with nulliparity.^89^
- One fair study reported that primiparous women were more likely to retain weight at 1 year postpartum than multiparous women.^141^

Table 50 Parity, gestational weight gain and outcomes

Outcome | Citations Addressing Effect of Parity | Effect of Parity
Preterm birth | 5^82,^,^83,87^–^89^ of 12^23,^,^59,^,^65,^,^71,^,^72,82^–^89^ | Lower gestational age with parity ≥ 5 compared with nulliparous; no significant association for other parities^83^ No significant association between preterm birth and parity^82,87^–^89^
Cesarean delivery | 4^67,^,^70,^,^72,76^ of 21^4,^,^25,^,^49,^,^51,^,^52,^,^54,^,^58,^,^59,^,^61,67^–^78^ | Higher risk of cesarean delivery with nulliparity^67,70^ Higher risk of cesarean delivery for nulliparity compared with parity = 1; no increased risk of cesarean with parity > 1 compared with parity =1^72^ Lower risk of cesarean with having had at least one viable pregnancy^76^
Birthweight | 8^48,^,^70,^,^83,^,^92,^,^98,^,^101,^,^102,105^ of 25^48,^,^54,^,^55,^,^59,^,^68,^,^70,^,^75,^,^83,90^–^106^ | Higher birthweight associated with higher parity^48,^,^70,^,^83,^,^92,^,^98,^,^101,^,^102,105^
Low birthweight | 2^70,109^ of 13^2,^,^4,^,^52,^,^54,^,^70,^,^71,^,^75,^,^93,^,^95,106^–^109^ | Lower risk of LBW with increased parity^70^ Lower risk of LBW with 3 or more term live births than with 1 or 2 live births; higher risk of LBW with no term live births than with 1 or 2^109^
Macrosomia | 3^70,^,^77,112^ of 12^2,^,^4,^,^49,^,^59,^,^70,^,^77,^,^93,^,^108,110^–^113^ | Higher risk of macrosomia with multiparity than with nulliparity^70,112^ Higher risk of macrosomia with nulliparity compared with parity ≥ 2, no significant risks of macrosomia with parity = 1 compared with parity ≥ 2^77^
LGA | 3^115,^,^116,122^ of 14^4,^,^54,^,^58,^,^59,^,^61,^,^68,^,^100,^,^105,^,^115,^,^116,^,^118,120^–^122^ | Higher risks of LGA with multiparity for all BMI categories^116^ Higher risks of LGA with multiparity^122^ No significant association between LGA and parity^115^
SGA | 3^66,^,^89,116^ of 20^4,^,^51,^,^54,^,^58,^,^59,^,^61,^,^66,^,^68,^,^89,^,^95,^,^105,^,^108,^,^111,^,^114,^,^116,^,^118,^,^119,122^–^124^ | Increased risk of IUGR for parity = 1 than with parity = 2; no increased risk of IUGR for parity ≥ 3 than with parity = 2^89^ Lower risk of SGA with multiparity for normal BMI women; no significant association between SGA and multiparity for underweight and overweight women^116^ Higher risk of SGA with nulliparity than multiparity^66^
Intermediate PPWR | 1^141^ of 5^140,^,^141,143^–^145^ | Lower risk of PPWR for primiparous women than multiparous women^141^

BMI, body mass index; IUGR, intra-uterine growth retardation; kg, kilogram; LBW, low birthweight; LGA, large-for-gestational-age; PPWR, postpartum weight retention; SGA, small for gestational age.

## KQ 4: Risks and Benefits of Gestational Weight Gain Recommendations

Despite conducting a systematic review of 150 studies identified by numerous search strategies, we did not uncover any clear exposition of the harms and benefits of offering the same weight gain recommendations to all women, irrespective of race or ethnicity, age, or pregravid BMI.

Although most studies controlled for various demographics variables in their analyses, few were specifically undertaken to understand the impact of the IOM recommendations on subpopulations. We did uncover a few studies that specifically investigated differential response to weight gain by pregravid BMI relative to numerous outcomes, but generally this evidence was not conclusive. Outcomes differentially affected by weight gain included the following:

- Labor induction (2 fair studies;^3,67^ 2 poor studies^59,68^)
- Cesarean delivery (9 fair studies;^4,^,^25,^,^58,69^–^73,^,^75,76^ 5 poor studies^51,^,^59,^,^61,^,^68,74^)
- Preterm birth (2 fair studies;^23,86^ 1 poor study^87^)
- Low birthweight(1 fair;^2^ 1 poor^162^ study)
- Large-for-gestational age(2 fair studies^25,129^)
- Macrosomia (2 fair studies^55,164^) and
- Postpartum weight retention (3 fair studies^138,^,^140,143^).

This differential response suggests that one recommendation for all women, irrespective of BMI, cannot be justified by the studies we reviewed. This conclusion is not as robust as it might seem, however, because nearly the entire database comprises observational studies; this fact renders the findings suggestive but not definitive. Further undermining our ability to state clearly whether any harms or benefits accrue to having a single recommendation for all women is that the quality ratings assigned to the studies were rarely “good” and that a nontrivial share of the articles were of poor quality and should be discounted in terms of arriving at overall grades of the strength of evidence. A common deficiency was that investigators did not control adequately for potential confounders and effect modifiers in their analyses. As noted throughout Chapter 3, inadequate attention to confounders undermines our ability to interpret the findings of much of the research we reviewed.

The IOM recommendations state that black women and teenagers should gain at the upper end of the recommendations; several researchers aimed to investigate whether weight gains differentially affect the outcomes for adolescents and black women. Assessing this research is important in determining the harms and benefits of one recommendation for all women.

### Findings Relative to Benefits and Harms of Different Recommendations Based on Race

The IOM guidelines recommended that black women gain at the upper end of recommended ranges; the aim was to influence differences in mean birthweights between blacks and whites and decrease the risks of low or suboptimal birthweights among black infants. Five studies, four good.^20,^,^116,^,^156,160^ and one fair,^85^ specifically aimed to compare the impact of the IOM guidelines on infants born to black and white women.

Three of these studies^20,^,^116,160^ did not produce evidence supporting benefits of black women gaining at the upper limit of the IOM recommendations. In one of the good studies,^116^ researchers studied 3,870 women who gave birth to singleton infants at 28 or more weeks of gestation between 1987 and 1989. They found that the relationship between weight gain and either SGA infants or LGA infants did not differ by maternal race for any BMI category. Although racial differences seemed to arise in the occurrence of SGA and LGA infants, these differences were mediated by pregravid BMI rather than weight gain during pregnancy. The researchers concluded that encouraging black women to gain at the upper end of the recommended range is unlikely to produce measurable reductions in SGA births; they noted, however, that benefits may accrue from recommending lowered weight gain recommendations for average and overweight white women with respect to the prevalence of LGA infants.

In another good study,^160^ investigators reported on data from the Pregnancy Nutrition Surveillance System for nine states. The study involved self-reported pregravid weight, total weight gain, and infant birthweight data on 173,066 women who delivered between 39 and 41 weeks' gestational age. Adjusted odds ratios (ORs) showed that both black and white women who entered pregnancy with a low BMI had a statistically greater likelihood of having an LBW infant if they gained 10 pounds or less than the IOM recommendations than did women who gained within the lower half of the recommendations. The investigators did not control for maternal complications and underlying diseases. Within all of the BMI-race strata, mean birthweight rose as weight gain increased. The study was unable to find consistent evidence to support benefits of counseling black women to gain at a rate different than that for other women; the researchers concluded that their analysis did not support the IOM recommendation that black women gain at the upper ends of the ranges.

The third study, which yielded no support for differential recommendations based on race, examined outcomes for 5,918 low-income women.^20^ The researchers revealed that adjusted mean birthweights were higher for white women with normal pregravid BMIs gaining in the upper half of the recommended ranges but not for black women with normal pregravid BMIs. They also found through logistic regression analyses that prenatal weight gain in the upper compared with the lower half of the recommended ranges was significantly associated with a decreased OR for low birthweight among white women but not for black women. In addition to its large size, the study has several strengths that included the exclusion of women with a variety of confounding characteristics, such as adolescents less than 18 years old and maternal risk factors for poor pregnancy outcomes. The researchers also excluded all women whose last prenatal weight assessment was greater than 3 weeks before delivery. The study lacked data on parity, however, and gestational age was not based on ultrasound verifications. Additionally, fewer black women than white women were included in the analyses, which may have limited the researchers' ability to detect the impact of weight gain on outcomes. Findings from the study led the researchers to conclude that their data do not support differential recommendations.

An earlier study by the same lead author had concluded that the IOM recommendation that black women gain at the upper end of the recommended ranges is valid.^156^ In this study, they analyzed birth outcomes for 1,168 multiparous low-income women who were at risk for delivering an SGA infant. When weight gain was less than 6 kg, black women with a pregravid BMI > 29 delivered twice as many growth-restricted infants as did white women with comparable BMIs; when, however, weight gain exceeded 6 kg, obese black women delivered one-third as many growth-restricted infants as obese white women. After adjusting for numerous potentially confounding and intervening variables, black women in each pregravid category delivered increasingly larger infants if they met or exceeded the IOM recommendations; this relationship effect was absent in white women. The authors concluded, therefore, that their findings supported the IOM recommendations regarding weight gain guidance for black women. This study lacked generalizability to all black women, however, because the study population was specifically chosen based on its risks for giving birth to growth-restricted infants.

The fifth study that specifically aimed to explore the interaction of weight gain and race on infant outcomes analyzed data from 15,101 births to white, black, Latina, and Asian women who entered pregnancy with normal or underweight BMIs.^85^ For most subgroups, weight gain beyond 0.27 kg per week was not associated with decreasing risks for spontaneous preterm births. However, both low and high weight gains were associated with significantly increased risks of spontaneous preterm birth in black women who had experienced a previous preterm birth and who entered pregnancy with a low or normal BMI. The authors concluded that determining whether race or ethnicity modifies the relationship between weight gain and prematurity requires further exploration.

In summary, the harms and benefits of providing women of all racial and ethnic subgroups with the same weight gain recommendations cannot be determined from existing research. Undoubtedly, various factors in addition to weight gain are likely to be responsible for differences between white and black women in both mean birthweights and the prevalence of low birthweight infants.^20^ As Hickey and colleagues note, more important than race may be social, economic, environmental, nutritional, cultural, lifestyle, medical and other factors for which race is a surrogate.^20^

### Findings Relative to Benefits and Harms of Different Recommendations Based on Age

Few studies specifically aimed to understand differences in the impact of weight gain recommendations on women in various age categories. Four studies purposefully investigated adolescents (1 good,^153^ 2 fair,^154,186^ and 1 poor^95^); according to the IOM, they should gain at the upper ranges of the BMI-specific recommendations.

Researchers for the one study rated good analyzed data for 815 black adolescents who, at the time of conceiving their infants, were less than 18 years old.^153^ Birthweight outcomes markedly improved in teens from all BMI groups when their weight gain increased from below to within the lower half of the IOM recommended range; additional benefits from gains in the upper half of the recommended ranges were modest or equivocal. A limitation of this study was that prepregnancy weight was self-reported; whether the reliability of self-reported weights in teens is equivalent to self-reported weights in older women is not known.

One fair study also reported results that question whether encouraging adolescents to gain in the upper ranges of the recommendations confers any advantages.^186^ This study specifically examined whether adolescents require greater prenatal weight gains than nonadolescents to deliver infants of comparable weight. The study population was 423 women between the ages of 14 and 25 who received care in a health maintenance organization. The study, published in 1991, did not specifically reference the IOM recommendations but, rather, used a weight gain of 11 to 12 kg as the optimal level. Both the adolescents and the young adults had a total weight gain of approximately 3 kg over the optimal level and delivered similar weight infants. Despite the relatively high weight gains, 28 percent of the adolescents and 31 percent of the nonadolescents had infants determined to be in the optimal weight range of 3,500 to 3,999 g. Maternal weight gain, gestational age, parity, and cigarette use during pregnancy were significant predictors of infant birthweight in the regression analysis. Analysis of subjects who were primiparous, nonsmokers, had a gestational age greater than 37 weeks at delivery, and who entered prenatal care in the first trimester revealed that mean monthly weight gain, total pregnancy weight gain, and infant birthweights were similar between the young adult and adolescent mothers. The authors concluded that pregnant adolescents are not at biological risk of delivering underweight infants and that adolescents do not appear to require a greater weight gain than young adults to deliver similar weight babies.

Another fair study undertook a prospective, longitudinal assessment to investigate the advantages and disadvantages of large weight gain among pregnant adolescents. The study involved 141 low-income black women ages 12 through 19. The subjects were classified according to their average rate of weekly weight gain as either slow, average, or rapid gainers. The rate of weight gain did not influence the prevalence of maternal glucose intolerance, pregnancy-induced hypertension, or cesarean delivery; larger weight gains were associated with larger infants.

One study did not meet inclusion criteria but we note it because it provides a provocative argument that weight gain recommendations based on adult BMI categories may not be sufficiently specific to yield optimal maternal and neonatal outcomes for childbearing adolescents.^187^ This study, which included only descriptive statistics and no multivariate analyses, compared the pregnancy experience of adolescents when assigned to IOM categories for BMI status with the experience when they were assigned to BMI growth curve percentiles set forth by the Centers for Disease Control and Prevention (CDC). Fewer adolescents were classified as underweight by the CDC BMI percentiles than by the IOM categories; thus, the CDC percentiles mean that fewer adolescents will be encouraged to gain extra pounds in pregnancy to compensate for low BMI. The author postulated that application of the IOM recommendations to teens results in recommendations for weight gain that are higher than necessary for healthy pregnancy outcomes and sets young women up for excess weight retention.

### Findings Relative to Benefits and Harms of Different Recommendations from the IOM

Options to the IOM weight gain recommendations were specifically explored in three studies (1 good;^188^ 2 fair^4,127^). These studies offered optimal weight gain ranges, based on their findings that differ from the IOM recommendations.

In a fair study, one research team set out to determine optimal weight gain in a singleton pregnancy.^127^ Using a retrospective cohort of 20,971 singleton pregnancies delivered in a primarily low-risk population between 1987 and 1993, the researchers reported that the best perinatal outcomes for all women, except those with BMIs in the obese range, occurred with higher weight gains than current IOM recommendations. The optimal gain was determined to be between 36 and 40 pounds; among obese women, the best outcomes occurred when women gained less than 36 pounds. These conclusions considered outcomes only for the infant without balancing the potential impact of such recommendations on prenatal and intrapartum complications for the mother or her long-term obesity risks.

Another study offered specific suggestions for women by obesity class defined by the National Institutes of Health (NIH).^4^ The authors, investigating the relationship between weight gain and preeclampsia, cesarean delivery, and LGA and SGA infants, reported that the following weight gains were associated with minimal risks for these outcomes: (a) class I obese women, weight gain of 10 to 25 pounds; (b) class II obese women, weight gain of 0 to 9 pounds; and (c) class III, obese women weight loss of 0 to 9 pounds. As noted earlier, this study failed to account for confounders and effect modifiers. A recent good study analyzed data from 298,648 singleton pregnancies registered in the Swedish Medical Birth Registry to recommend optimal weight gains by BMI class.^188^ Analyzing the ORs of various adverse maternal and perinatal outcomes, the researchers determined that the optimal weight gains were as follows: (a) for women entering pregnancy with a BMI < 20, 9 to 22 pounds (4–10 kg); (b) for women with a BMI of 20 to 24.9, 5 to 22 pounds (2–10 kg); for women with BMIs of 25 to 29.9, less than 20 pounds (< 9 kg); and (d) for women with a BMI ≥ 30, less than 13 pounds (< 6 kg). Like most studies in this review, it limited its exploration to short-term outcomes related to the pregnancy, the intrapartum, and the neonatal period.

The most compelling evidence to determine the harms and benefits of the IOM recommendations compared with those of other recommendations would come from experimental studies. The IOM recommendations have become the de facto standard of care, however, and so investigators have neither an incentive nor an ethically strong position to test alternatives.

### Conclusions Regarding the Harms and Benefits of Uniform Recommendations for All Women

In conclusion, existing research is inadequate to assess objectively the range of harms and benefits of providing all women, irrespective of age, race or ethnicity, or pregravid BMI with the same recommendation for weight gain in pregnancy. The majority of the studies presented evidence suggesting that one recommendation for all women would be disadvantageous, but findings were not consistent; moreover, these studies typically did not fully explore harms. Most of the studies in this review limited their analyses to short-term outcomes related to the pregnancy, the intrapartum, and the neonatal period. A full examination of harms would require longitudinal cohorts to determine long-term and unexpected consequences of specific recommendations.

A major impediment in understanding the harms or benefits of offering the same weight gain recommendations to all women is the lack of any information about how that advice might have been proffered. That is, the research we included did not reveal studies that investigated the processes of offering advice or the behavioral determinants for women acting on advice that is offered.

## KQ 5: Anthropometrics of Weight Measurement During Pregnancy

Clinicians and researchers can use several anthropometric tools to determine adiposity (body fat). They include height and weight (to derive BMI); skinfold thicknesses, measured with calipers at various regions of the body, such as the arms, legs, and abdomen; circumferences, measured with measuring tape at various regions of the body, such as the arms, hips, and waist; bioelectrical impedance analysis (BIA); ultrasound; isotope dilution (to assess total body water); total body potassium; dual energy x-ray absorptiometry (DEXA); underwater or hydrostatic weighing (to measure body density); computerized tomography (CT); and magnetic resonance imaging (MRI).

The majority of these tools are appropriate for measuring adiposity in the pregnancy state (Table 51). The exceptions are CT and DEXA, which involve x-ray energies, and BIA, which has been used in pregnant women; however, its appropriateness is questionable because it involves sending a weak electrical current through the body.

Table 51 Adiposity measurements and use in pregnancy

Adiposity Measurement | Used During Pregnancy?
Weight | Yes
Body mass index (BMI) | Yes
Skinfold thicknesses | Yes
Circumferences | Yes
Hydrostatic weighing | Yes
Dual energy x-ray absorptiometry (DEXA) | No
Bioelectrical impedance analysis (BIA) | Yes
Isotope dilution | Yes
Total body potassium | Yes
Total body nitrogen | Yes
Computed tomography (CT) | No
Magnetic resonance imaging (MRI) | Yes
Ultrasound | Yes

Because body fat cannot be measured directly, researchers can incorporate values obtained from these tools into various equations to estimate percent body fat or body fat mass. These methods have been evaluated in two fair-quality studies.^16,180^ The equations and models, such as the four-compartment model, are based on assumptions of the relationships between aspects of body composition that can and cannot be measured. The more assumptions that a model relies on, the less likely it is to be accurate, especially when those assumptions are for large body components, such as water and bone.^180^ The four-compartment model, which incorporates measurements of total body water, body density, body weight, and bone mineral content, has been shown to be a more accurate approach to estimating body fat^16,180^ than other equations using skinfolds and circumferences.

An obstacle in trying to assess body composition during pregnancy is that body components (e.g., water, lean mass, fat) are constantly changing throughout gestation; moreover, some measurements may not be able to distinguish individual components. For example, increased fluid retention and subcutaneous fat deposition during pregnancy may result in greater skinfold thickness estimates. If body fat or body density estimates are derived from equations using skinfold thicknesses, then body fat will be overestimated.^180^ Additionally, anthropometric equations may be based on reference data collected in nonpregnant women or in those who are in early pregnancy and therefore involve inaccurate assumptions of changes occurring throughout pregnancy.

The lack of research on anthropometric changes throughout pregnancy and the postpartum period using measurements other than body weight and BMI is notable. Furthermore, only limited information is available about the methodology, validity, comparability, and, in some cases, safety of these measurements during pregnancy. Although ultrasound techniques are used throughout pregnancy and have been validated for measuring visceral fat, they are seldom used for measuring maternal adiposity. Similarly, MRI may be an effective tool to estimate adiposity; however, machinery is not readily available and is expensive to operate, therefore limiting its use in research settings. In contrast, measurements such as skinfold thicknesses or circumferences are inexpensive and easy to collect in the clinical setting, but whether they are as or more informative or predictive of infant and maternal outcomes than standard body weight and height measurements remains unclear. These types of measurements also require training and standardized methods (e.g., where tape measures or calipers are placed and how measurements are made); these requirements, especially if not met, may yield less precise and reproducible measurements than more expensive and sophisticated methods.

## Limitations

### Limitations of the Evidence Base

Source of information on weight gain. The lack of attention to the validity of self-reported weight and weight gain is a key limitation of this evidence base. Studies typically relied on self-report for pregravid weight; a substantial proportion relied on self-report for weight gain as well. Women often misreport their weight, and this bias varies by weight status. One study found underreporting of BMI (kg/m^2^) by 0.8 and an understated prevalence of overweight or obesity (BMI > 25) in the range of 3 percent to 5 percent for non-Hispanic black and white women and up to 16 percent for Mexican-American women.^39^ Among obese women of reproductive age, 50 percent underreported their weight by more than 5 pounds.^38^ When studies use self-reports for both pregravid weight and weight gain during pregnancy, the bias is likely compounded.

Timing of measurement of gestational weight gain. Related to the issue of estimating the measurement error in the calculation of gestational weight gain is the timing of weight measurement during pregnancy relative to gestational age. Few women are weighed at the time of delivery; thus, their weight at the last prenatal visit varies by gestational age. Adjusting for the timing in gestation is critical in assessing adequacy of weight gain.

Studies fail to account for gestational age for other outcomes of interest as well. GDM is customarily diagnosed at about 26 to 28 weeks' gestation; for that reason, weight gain up to the time of the GDM diagnosis is the critical exposure period, not total weight gain during pregnancy. With outcomes such as preeclampsia, the timing of measurement is critical because increased weight gain that may be attributable to edema may be related to the disease process itself.

Studies that examine the effect of weight gain by trimesters of pregnancy but that fail to account for gestational age at the first weight measurement also suffer from likely misestimation of the true amount of weight gained early in pregnancy. Results from such studies may be biased as a result.

Appropriate adjustment for confounding. The evidence base is also limited by variations in the specific confounders and effect modifiers that investigators included or controlled for in their analyses. Omission of important confounders and effect modifiers, especially complications of pregnancy that are associated with changes in maternal weight postpartum, intrapartum complications, or birthweight, limit the interpretability and utility of the evidence. Furthermore, using the studies that did account for confounders and effect modifiers is hampered by the lack of consistent definition and inclusion of key variables.

These deficiencies together appreciably limit the consistency and validity of the evidence. As a result, we found very few outcomes for which we were able to attribute at least a moderate strength of association, despite the relatively large body of evidence that we examined.

### Limitations of the Review

We limited our search to articles published in English, primarily for reasons of time and resources. We also excluded case reports and case series with fewer than 100 women. Given the deficiencies of much of the work we did include, however, we do not believe that these exclusions would have provided much, if any, additional useful information. We did examine work from numerous developed countries, so our review does reach beyond the United States and potentially beyond English-speaking countries.

For similar time and resource reasons, we did not conduct dual independent, blinded review of articles for inclusion or abstraction of information into evidence tables. Instead, one reviewer performed the initial review, and a second reviewer examined that input and recommended changes or corrections when needed. These two reviewers reconciled any differences by consensus discussion. These procedures are generally in accord with the usual procedures for the RTI-UNC Evidence-based Practice Center. To enable us to address any systematic bias in our work that the above approach may have introduced, however, we did apply dual independent review for assessing the quality of individual articles and grading the strength of evidence.

The paucity of “similar” articles, for populations, patient characteristics, settings, and outcomes measured, precluded any efforts to pool findings statistically.

## Future Research Directions

The gold standard of a randomized controlled trial will never be appropriate to determine the impact of different levels of weight gain by women of varying pregravid weights relative to their own health, the health of their pregnancy, and the health of the offspring. Therefore, observational studies are necessary to determine associations. Although our systematic review included large numbers of studies that took advantage of large databases and longitudinal data that allowed investigation of the influence of weight gain on short- and long-term outcomes, it yielded very little in the way of consistent findings because the body of research lacks methodological rigor, precision, and directionality.

Major shortcomings in the existing research include the lack of uniformity in definitions of the exposure and outcomes, lack of structured and transparent approaches for assessing confounders and effect modification, lack of power to detect meaningful differences, and inadequate approaches for assessing multiple outcomes related to gestational weight gain for the mother and child. Many studies also failed to provide a conceptual model that accounted for physiological processes. A comprehensive conceptual model with biological underpinnings would have allowed for the identification of preexisting maternal conditions that could confound the relationship between weight gain during pregnancy and outcomes such as gestational diabetes, pregnancy-induced hypertension, and newborn weight.

Another major shortcoming of the existing research is that many of the retrospective cohorts reported on populations preceding the obesity epidemic in this country. In addition, the IOM recommendations are imprecise with respect to overweight and obese women. The obese population deserves special attention because they are likely to enter pregnancy with numerous coexisting conditions or problems; they are also more likely to develop complications in pregnancy such as gestational diabetes, pregnancy-induced hypertension, preeclampsia, and delivery by cesarean section.

To address methodological issues future studies should:

- State when and how baseline pregravid weight and height are determined;
- When weight is self-reported, check for biological plausibility;
- State when and how weight gain is determined;
- Specify when and how postpartum weight is determined;
- Report on how outliers in pregravid weight, gestational weight gain, postpartum weight, and maternal height are handled;
- Standardize definitions regarding rates of weight gain, adequacy of rate of weight gain, and total weight gain;
- Standardize definitions of key confounders and effect modifiers, with more attention directed to disease states that affect both weight gain and pregnancy and neonatal outcomes; and
- Use more specific categories of BMI status for women categorized as obese (for example, using NIH categories such as obese class I, II, and III).

Most of the reviewed studies relied on self-reported pregravid weight and argued that this is an acceptable surrogate for prepregnancy measurement because it has been demonstrated in some populations to be reliable. That reliability needs to be studied for women of varying pregravid weights; it also needs to be studied relative to when it is asked in gestation (e.g., early first trimester, second trimester, or at delivery). Without a thorough understanding of the reliability of self-reported weights in and beyond pregnancy for all women and for subpopulations of women by age, BMI, and race or ethnicity, calculations for total weight gain may well lead researchers to conclusions supported by the data but not by actual weight changes. Such errors in calculations could easily lead to erroneous or missed associations. Thus, studies that assess the magnitude of this error are urgently needed.

We identified the following areas for further studies:

- Exploration of whether women receive accurate weight gain guidance by their prenatal clinicians; whether clinicians have the knowledge, attitudes, and skills necessary to provide appropriate weight gain guidance
- The knowledge, attitudes, and self-efficacy of women regarding gestational weight gain
- The impact of weight gain on lactation performance in order to differentiate biologic and psychologic reasons for discontinuation of breastfeeding
- The impact of age (younger and older) on the relationship of weight gain and pregnancy outcomes
- The impact of menarchal age on the relationship of weight gain and pregnancy outcomes
- The impact of parity on the relationship of weight gain and pregnancy outcomes
- Genetic influences of the relationship between weight gain and pregnancy outcomes
- The effect, over time, of gestational weight gain on women's health status
- The interaction of stature and weight gain
- Tests of the reliability of self-reported weights in pregnancy by age, parity, and BMI
- The impact of total weight gain vs. rate of weight gain vs. timing of weight gain on pregnancy outcomes
- Tests of the use of direct measurements of body fat prior to and during pregnancy as well as in the postpartum period
- Preferred anthropometric measurements for predicting outcomes of interest
- The effect of gestational weight gain on infant (beyond birthweight) and childhood outcomes
- Determination of optimal weight gains for obese women

In addition, more research is needed to evaluate the long-term impact of specific amounts of weight gain. This research will require significant funding because following longitudinal cohorts is crucial. Scandinavian countries report on longitudinal cohorts, but findings from these studies lack reasonable generalizability to the United States, which has a far more diverse population, a different prevalence of obesity, possibly different norms about the acceptability of obesity, and a different structure for health care delivery.

Finally, we emphasize the need for the use of far better research methods than the existing body of evidence reflects. Clearly the field has improved over time in the use of analytical approaches; more recent studies have taken into consideration some of the flaws in previous work. Investigators should make use of checklists to improve the quality of reporting of observational studies, such as STROBE,^189^ to ensure that the design and conduct of their work meets contemporary standards for publication.