# Introduction

This systematic review of outcomes of maternal weight gain, often referred to as gestational weight gain,^*^ is motivated by several trends in perinatal health that are of great public health concern. First, since 1990, women have increasingly gained weight during pregnancy beyond the thresholds set forth by the Institute of Medicine (IOM);^1^ these increases are pronounced among overweight and obese women.^2^–^4^ Second, overweight and obesity levels among women of childbearing ages are rising dramatically^5^–^8^ as are the levels among preschool children.^9^ Third, pregnancy complications associated with excess weight such as gestational diabetes and large-for-gestational-age babies^10^ and cesarean delivery^11^ have increased in prevalence. These trends, coupled with the limitations of the current guidelines, point to the need for assessment of the guidelines to address optimal weight gain for all women during pregnancy.

* Hereafter in this report, we refer to gestational weight gain for consistency across the text and to clarify that we focus on weight gained during gestation as the exposure of interest.

## Background

### Weight Gain Recommendations in the United States

Ideal weight gain during pregnancy has long been debated. Gestational (formerly maternal) weight gain includes the products of conception, which include the fetus and placenta, and increases in maternal fat stores, plasma volume, and uterine and breast tissue. Because pregnancy is the only common clinical situation when the provider has at least two patients, the mother and the fetus(es), balancing the amount of weight gain needed to optimize the size of the baby without jeopardizing the health of the mother both in the short and long term is essential. The balance has proven challenging.

In the 1930s, the recommendation to all pregnant women, irrespective of pregravid weight status, was 6.8 kg (~ 15 pounds). This recommendation to restrict weight gains to decrease the risk of pregnancy complications continued until 1970; it stemmed largely from the observation that increased maternal weight gains were positively related to higher birthweights.^12^ In 1970, however, the IOM determined that restriction of weight gain was likely to be harmful with respect to birthweight; subsequently, weight gain recommendations were eased from less than 20 pounds throughout pregnancy to a range of 20 to 27 pounds.^13^

Over the next two decades, accumulating research suggested that one guideline was unlikely to benefit all women and their fetuses. This recognition led an IOM committee to issue guidelines that offered standardized guidance to providers and to the general public based on a woman's pregravid weight status.^1^ The recommendations were weight gains of (a) 28 to 40 pounds for women with low body mass index (BMI), defined as < 19.8; (b) 25 to 35 pounds for women with normal BMI (19.8–26); and (c) 15 to 25 pounds for women with high BMI (> 26.0–29.0). Further, the recommendations included a weight gain of at least 15 pounds for obese women (BMI > 29), weight gain in the upper end of the recommended range for adolescents and black women, and weight gain in the lower end of the recommended range for short women (< 157 centimeters [cm] or 62 inches).

These recommendations were the first to account for pregravid weight status and to encourage obese women to gain weight during pregnancy in recognition of the needs of the fetus. They also addressed patterns of weight gain by providing guidance on the ideal amount to be gained in the first trimester and rates of weight gain in the second and third trimesters. These recommendations tended to focus on the prevention of low birthweight deliveries rather than the impact on maternal obesity and related health outcomes.

In 1996, an expert panel assembled by the Maternal and Child Health Bureau of the US Health Resources and Services Administration reexamined these recommendations. At the time, the panel decided that revisions were unnecessary. They found, however, that the evidence to date suggested that the recommendations for higher weight gains by black women and adolescents and lower weight gains for women of short stature were not well supported; they concluded that these subpopulations should be advised to stay within the IOM's recommended weight range specific for their pregravid BMI.^14^

### Gestational Weight Gain Patterns in the United States

Since the 1990 IOM recommendations appeared, several studies have documented the proportion of women meeting the guidelines. In a 1998 study of more than 120,000 women, only 34 percent gained weight within the recommended ranges.^15^ Specifically, the proportion of women gaining more than the recommended range increased over the time span from 42 percent to 44 percent. The figures for women gaining less than the recommended amount remained relatively stable over time (23 percent to 22 percent). Other studies reporting on various subpopulations since the 1990 report found that only 30 percent to 40 percent of women gained weight within the recommended ranges.^4,16^–^25^ Although the IOM recommendations have been in existence for almost 2 decades, between 35 percent and 60 percent of pregnant women reported receiving no advice from their providers about appropriate pregnancy weight gain.^26,27^ Pregnant women who reported being advised about the appropriate amount of weight to gain during pregnancy were more likely to gain within the recommended range than women who did not report receiving such advice.^28,29^ This association is based on a handful of studies; moreover, most had been conducted before or soon after the revised IOM guidelines were made public.^26,^,^28,29^

Persistent nonadherence to weight gain guidelines and the wide variability in the amount of weight gained during pregnancy has served as the impetus for much research on predictors of the adequacy of gestational weight gain. This body of work suggests that a multifactorial model may be at play.^27,^,^30,31^ The bulk of research in this area has emphasized the importance of pregravid weight status, parity, height, race or ethnicity, age, age at menarche, physical activity, and psychosocial stress.^27,30^–^33^ Although such investigations are important, even more basic is an understanding of the short- and long-term benefits and risks of gestational weight gain for the mother, the fetus, and the child. This systematic evidence review was undertaken to fully explore what has been learned about the impact of gestational weight gain since the IOM recommendations were released in 1990.

## Key Questions and Analytic Framework

### Key Questions

Increases in the body weight of women of childbearing ages combined with a rising trend in weight gain during pregnancy outside the IOM recommendations have raised concerns about the 1990 IOM recommendations. Of particular interest is assembling and evaluating evidence linking gestational weight gain and birth, infant, and maternal health outcomes.

To accomplish this, the Agency for Healthcare Research and Quality (AHRQ) commissioned the RTI International-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) to complete this systematic review. The partner for this work was the American Dietetic Association. The EPC received and revised key questions (KQs) after discussions with internal technical staff, AHRQ staff, an American Dietetic Association representative, and our Technical Expert Panel (TEP, see below). The final KQs are as follows:

KQ 1. What is the evidence that either total weight gain or rate of weight gain during pregnancy is associated with (1) birth outcomes, (2) infant health outcomes, and (3) maternal health outcomes? Does any evidence suggest that either total weight gain or rate of weight gain is a causal factor in infant or maternal health outcomes?

KQ 2. What are the confounders and effect modifiers for the association between maternal weight gain (overall and patterns) and birth outcomes? Based on the findings in KQ 1, do these confounders and effect modifiers themselves contribute to antepartum or postpartum complications or to longer-term maternal and fetal complications, including development of adult obesity?

KQ 3. What is the evidence that weight gains above or below thresholds defined in the 1990 Institute of Medicine BMI Guidelines or weight loss in pregnancy contribute to antepartum or postpartum complications or longer-term maternal and fetal complications? How do these relationships vary by sociodemographic characteristics (i.e., race and age)?

KQ 4. What are the harms or benefits of offering the same weight gain recommendations to all pregnant women, irrespective of age and body weight considerations (e.g., pregravid weight, actual body weight at a particular time point, or optimal body weight)?

KQ 5. What are the anthropometric tools for determining adiposity and their appropriateness for the pregnancy state? What are the risks and benefits of measuring adiposity for (1) clinical management of weight gain during pregnancy and (2) evaluation of the relationship between weight gain and outcomes of pregnancy?

## Analytic Framework for Outcomes of Maternal Weight Gain

The analytic framework adopted from the 1990 IOM report shown in Figure 1 (i.e., the conceptual model developed to guide this systematic review) summarizes the critical topics addressed by this report and their links to the key questions. KQs 1 and 3 focus on identifying and evaluating evidence. KQ 5 attempts to explore the practicality and clinical utility of methods to assess maternal fat accrual (often thought to be the causative agent for many of the adverse outcomes).^34^ KQs 2 and 4 are essentially derivative of information obtained for KQs 1 and 3.

Figure 1. Outcomes of gestational weight gain for singleton pregnancies: conceptual framework

The KQs are noted on the relevant arrows connecting the main boxes or within boxes, as appropriate. Our conceptual framework recognizes that energy balance, which is a result of dietary intake and energy expenditure, directly influences maternal weight gain. We note, however, that this systematic review focuses on outcomes of weight gain during pregnancy, not on the predictors of that weight gain. As a result, we do not directly address strategies to reduce or modify maternal weight gain. Furthermore, this field of research consists predominantly of observational studies, which by their nature do not prove causality and, at most, provide evidence on a temporal sequence of events. The majority of the studies included in this systematic review are observational in nature. For that reason, we do not infer causality between gestational weight gain and health outcomes and instead focus on the strength of association.

## Production of This Evidence Report

### Organization of This Evidence Report

Chapter 2 describes our methods, including our search strategies and inclusion/exclusion criteria; we also document our approach to grading the quality of articles and rating the strength of evidence. We conducted extensive systematic literature searches and appraisal of evidence for included articles only for KQs 1, 3, and 5. In Chapter 3, we report the results of literature searches and synthesis of retained articles for KQs 1, 2, 3, and 5. Chapter 4 presents our conclusions and discusses KQ 4 in detail; it also offers our recommendations for future research.

References and included studies follow Chapter 4. Appendixes include a detailed description of our search strings (Appendix A), ^†^ data collection forms (Appendix B), detailed evidence tables (Appendix C), excluded studies (Appendix D), and acknowledgments (Appendix E).

† Appendixes and evidence tables cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/admaternal/admaternalapp.pdf.

### Technical Expert Panel (TEP)

We identified six technical experts in nutrition, nursing, obstetrics, and family medicine to provide assistance throughout the project (Appendix E); one was a member of the American Dietetic Association. The TEP contributed to AHRQ's broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products. Thus, the TEP was both an additional resource and a sounding board during the project.

To ensure robust, scientifically relevant work, we called on the TEP to provide reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. Specifically, TEP members participated in conference calls and discussions through e-mail to:

- refine the analytic framework and key questions at the beginning of the project;
- discuss the preliminary assessment of the literature, including inclusion/exclusion criteria; and
- provide input on the information and categories included in evidence tables.

Because of their extensive knowledge of the literature, including numerous articles authored by TEP members themselves, and their active involvement in professional societies and as practitioners in the field, we also asked TEP members to participate in the external peer review of the draft report.

## Uses of This Report

This evidence report addresses the key questions outlined above using methods described in Chapter 2 to conduct a systematic review of published literature. We anticipate that the report will be of value to all women's health care providers, including the American Dietetic Association, the American College of Obstetricians and Gynecologists, the American College of Nurse Midwives, the Association of Women's Health, Obstetric and Neonatal Nurses, the American Society of Reproductive Medicine, and other groups concerned with health outcomes during childbearing and beyond, such as the American Academy of Family Physicians and the American Academy of Nurse Practitioners, and the American Academy of Pediatrics. This report can bring practitioners up to date about the current state of evidence, and it provides an assessment of the quality of studies that aim to determine the outcomes of maternal weight gain.

The report will be of use to various parts of the US Department of Health and Human Services, including the National Institutes of Health, Centers for Disease Control and Prevention, Centers for Medicare & Medicaid Services, and Health Resources and Services Administration, and the US Department of Agriculture; all these agencies have offices or bureaus devoted to women's health issues. We also anticipate that it will be of use to private sector organizations concerned with women's health, such as Our Bodies Ourselves, the National Women's Health Network, and the National Black Women's Health Imperative. In addition, this review will be of use to the Institute of Medicine in proposed revisions to the national guidelines.

Researchers can obtain a concise analysis of the current state of knowledge in this field. They will be poised to pursue further investigations that are needed to understand the causal links between maternal weight gain and health outcomes for mother and baby, clarify risk factors, develop prevention strategies, and optimize guidelines offered to women.