# Acronyms and Abbreviations

ACOG | American College of Obstetrics and Gynecology
AHRQ | Agency for Healthcare Research and Quality
ART | Assisted reproductive technology
ASRM | American Society for Reproductive Medicine
BMI | Body mass index
CC | Clomiphene citrate
CDC | Centers for Disease Control and Prevention
CI | Confidence interval
FDA | U.S. Food and Drug Administration
FSH | Follicle-stimulating hormone
GIFT | Gamete intrafallopian transfer
GnRH | Gonadotropin-releasing hormone
hCG | Human chorionic gonadotropin
HEPES | n-hydroxyethylpiperazine-n-ethanesulfonate
hMG | Human menopausal gonadotropin
HRQOL | Health-related quality of life
ICI | Intracervical insemination
ICSI | Intracytoplasmic sperm injection
IUI | Intrauterine insemination
IVF | In vitro fertilization
LH | Luteinizing hormone
NICU | Neonatal intensive care unit
NIH | National Institutes of Health
NNT | Number-needed-to-treat
NSAID | Non-steroidal anti-inflammatory drug
OCP | Oral contraceptive pill
OHSS | Ovarian hyperstimulation syndrome
OR | Odds ratio
ORWH | Office of Research on Women's Health
PCOS | Polycystic ovarian syndrome
PGD | Preimplantation genetic diagnosis
PPCOS | Pregnancy in Polycystic Ovary Syndrome study
RCT | Randomized controlled trial
rFSH | Recombinant follicle-stimulating hormone
rhCG | Recombinant human chorionic gonadotropin
rLH | Recombinant luteinizing hormone
RR | Relative risk
SART | Society for Assisted Reproductive Technology
SGA | Small for gestational age
SIR | Standardized incidence ratio
uFSH | Urinary follicle-stimulating hormone
ZIFT | Zygote intrafallopian transfer