# List of Included Studies (Questions 2–4, in Alphabetical Order)

Aboulghar H, Aboulghar M, Mansour R, et al. A prospective controlled study of karyotyping for 430 consecutive babies conceived through intracytoplasmic sperm injection. Fertil Steril. 2001;76(2):249-53. [pmid: 11476768].
Aboulghar MA, Mansour RT, Serour GI, et al. Increasing the dose of human menopausal gonadotrophins on day of GnRH antagonist administration: randomized controlled trial. Reproductive Biomedicine Online. 2004;8(5):524-7. [pmid: 15151713].
Adler-Levy Y, Lunenfeld E, Levy A. Obstetric outcome of twin pregnancies conceived by in vitro fertilization and ovulation induction compared with those conceived spontaneously. Eur J Obstet Gynecol Reprod Biol. 2007;133(2):173-8. [pmid: 17056174].
Agarwal P, Loh SK, Lim SB, et al. Two-year neurodevelopmental outcome in children conceived by intracytoplasmic sperm injection: prospective cohort study. BJOG. 2005;112(10):1376-83. [pmid: 16167940].
Al-Fadhli R, Sylvestre C, Buckett W, et al. A randomized trial of superovulation with two different doses of letrozole. Fertil Steril. 2006;85(1):161-4. [pmid: 16412748].
Al-Fozan H, Al-Khadouri M, Tan SL, et al. A randomized trial of letrozole versus clomiphene citrate in women undergoing superovulation. Fertil Steril. 2004;82(6):1561-3. [pmid: 15589860].
Albano C, Felberbaum RE, Smitz J, et al. Ovarian stimulation with HMG: results of a prospective randomized phase III European study comparing the luteinizing hormone-releasing hormone (LHRH)-antagonist cetrorelix and the LHRH-agonist buserelin. European Cetrorelix Study Group. Hum Reprod. 2000;15(3):526-31. [pmid: 10686191].
Ali Hassan H, El-Gezeiry D, Nafaa TM, et al. Improved responsiveness of PCOS patients to clomiphene after CYP17a inhibitor. J Assist Reprod Genet. 2001;18(11):608-11. [pmid: 11804430].
Alikani M, Cekleniak NA, Walters E, et al. Monozygotic twinning following assisted conception: an analysis of 81 consecutive cases. Hum Reprod. 2003;18(9):1937-43. [pmid: 12923153].
Allegra A, Marino A, Coffaro F, et al. GnRH antagonist-induced inhibition of the premature LH surge increases pregnancy rates in IUI-stimulated cycles. A prospective randomized trial. Hum Reprod. 2007;22(1):101-8. [pmid: 17032732].
Alleyassin A, Khademi A, Aghahosseini M, et al. Comparison of unilateral and bilateral transfer of injected oocytes into fallopian tubes: a prospective, randomized clinical trial. Fertil Steril. 2006;85(1):96-100. [pmid: 16412737].
Andersen AN, Devroey P, Arce JC. Clinical outcome following stimulation with highly purified hMG or recombinant FSH in patients undergoing IVF: a randomized assessor-blind controlled trial. Hum Reprod. 2006;21(12):3217-27. [pmid: 16873892].
Anthony S, Buitendijk SE, Dorrepaal CA, et al. Congenital malformations in 4224 children conceived after IVF. Hum Reprod. 2002;17(8):2089-95. [pmid: 12151442].
Ata B, Isiklar A, Balaban B, et al. Prospective randomized comparison of Wallace and Labotect embryo transfer catheters. Reproductive Biomedicine Online. 2007;14(4):471-6. [pmid: 17425830].
Avrech OM, Orvieto R, Pinkas H, et al. Inclusion of standard and low-dose gonadotropin releasing hormone-analog (short protocol) in controlled ovarian hyperstimulation regimens in normogonadotropic patients aged 40–48 years who are undergoing in vitro fertilization. Gynecol Endocrinol. 2004;19(5):247-52. [pmid: 15726912].
Babayof R, Margalioth EJ, Huleihel M, et al. Serum inhibin A, VEGF and TNFalpha levels after triggering oocyte maturation with GnRH agonist compared with HCG in women with polycystic ovaries undergoing IVF treatment: a prospective randomized trial. Hum Reprod. 2006;21(5):1260-5. [pmid: 16439507].
Badawy A, Baker El Nashar A, El Totongy M. Clomiphene citrate plus N-acetyl cysteine versus clomiphene citrate for augmenting ovulation in the management of unexplained infertility: a randomized double-blind controlled trial. Fertil Steril. 2006;86(3):647-50. [pmid: 16831439].
Bahceci M, Ulug U, Ben-Shlomo I, et al. Use of a GnRH antagonist in controlled ovarian hyperstimulation for assisted conception in women with polycystic ovary disease: a randomized, prospective, pilot study. J Reprod Med. 2005;50(2):84-90. [pmid: 15755044].
Bahceci M, Ulug U, Ciray HN, et al. Efficiency of changing the embryo transfer time from day 3 to day 2 among women with poor ovarian response: a prospective randomized trial. Fertil Steril. 2006;86(1):81-5. [pmid: 16716322].
Bajoria R, Ward SB, Adegbite AL. Comparative study of perinatal outcome of dichorionic and trichorionic iatrogenic triplets. Am J Obstet Gynecol. 2006;194(2):415-24. [pmid: 16458639].
Balaban B, Yakin K, Isiklar A, et al. Utilization of high-security straws for embryo freezing in an in vitro fertilization program: a prospective, randomized study. Fertil Steril. 2007;87(3):691-6. [pmid: 17173906].
Balasch J, Creus M, Fabregues F, et al. The effect of exogenous luteinizing hormone (LH) on oocyte viability: evidence from a comparative study using recombinant human follicle-stimulating hormone (FSH) alone or in combination with recombinant LH for ovarian stimulation in pituitary-suppressed women undergoing assisted reproduction. J Assist Reprod Genet. 2001;18(5):250-6. [pmid: 11464575].
Balasch J, Fabregues F, Creus M, et al. Follicular development and hormone concentrations following recombinant FSH administration for anovulation associated with polycystic ovarian syndrome: prospective, randomized comparison between low-dose step-up and modified step-down regimens. Hum Reprod. 2001;16(4):652-6. [pmid: 11278212].
Barmat LI, Chantilis SJ, Hurst BS, et al. A randomized prospective trial comparing gonadotropin-releasing hormone (GnRH) antagonist/recombinant follicle-stimulating hormone (rFSH) versus GnRH-agonist/rFSH in women pretreated with oral contraceptives before in vitro fertilization. Fertil Steril. 2005;83(2):321-30. [pmid: 15705369].
Baruffi R, Mauri AL, Petersen CG, et al. Effects of vaginal progesterone administration starting on the day of oocyte retrieval on pregnancy rates. J Assist Reprod Genet. 2003;20(12):517-20. [pmid: 15035552].
Baruffi RL, Mauri AL, Petersen C, et al. Day 2 vs. day 3 embryo transfer after intracytoplasmic sperm injection. A prospective, randomized study. J Reprod Med. 2003;48(8):631-4. [pmid: 12971145].
Baruffi RL, Mauri AL, Petersen CG, et al. Zona thinning with noncontact diode laser in patients aged < or = 37 years with no previous failure of implantation: a prospective randomized study. J Assist Reprod Genet. 2000;17(10):557-60. [pmid: 11212860].
Battaglia C, Regnani G, Marsella T, et al. Adjuvant L-arginine treatment in controlled ovarian hyperstimulation: a double-blind, randomized study. Hum Reprod. 2002;17(3):659-65. [pmid: 11870119].
Bayar U, Tanriverdi HA, Barut A, et al. Letrozole vs. clomiphene citrate in patients with ovulatory infertility. Fertil Steril. 2006;85(4):1045-8. [pmid: 16580393].
Bayram N, van Wely M, Kaaijk EM, et al. Using an electrocautery strategy or recombinant follicle stimulating hormone to induce ovulation in polycystic ovary syndrome: randomised controlled trial. BMJ. 2004;328(7433):192. [pmid: 14739186]. [pmcid: 318481].
Baysoy A, Serdaroglu H, Jamal H, et al. Letrozole versus human menopausal gonadotrophin in women undergoing intrauterine insemination. Reproductive Biomedicine Online. 2006;13(2):208-12. [pmid: 16895634].
Beckers NG, Laven JS, Eijkemans MJ, et al. Follicular and luteal phase characteristics following early cessation of gonadotrophin-releasing hormone agonist during ovarian stimulation for in-vitro fertilization. Hum Reprod. 2000;15(1):43-9. [pmid: 10611186].
Bellver J, Munoz EA, Ballesteros A, et al. Intravenous albumin does not prevent moderate-severe ovarian hyperstimulation syndrome in high-risk IVF patients: a randomized controlled study. Hum Reprod. 2003;18(11):2283-8. [pmid: 14585874].
Belva F, Henriet S, Liebaers I, et al. Medical outcome of 8-year-old singleton ICSI children (born >or=32 weeks' gestation) and a spontaneously conceived comparison group. Hum Reprod. 2007;22(2):506-15. [pmid: 16982659].
Ben-Ami I, Vaknin Z, Reish O, et al. Is there an increased rate of anencephaly in twins?. Prenat Diagn. 2005;25(11):1007-10. [pmid: 16231303].
Ben-Yosef D, Amit A, Azem F, et al. Prospective randomized comparison of two embryo culture systems: P1 medium by Irvine Scientific and the Cook IVF Medium. J Assist Reprod Genet. 2004;21(8):291-5. [pmid: 15568329].
Benshushan A, Paltiel O, Brzezinski A, et al. Ovulation induction and risk of endometrial cancer: a pilot study. Eur J Obstet Gynecol Reprod Biol. 2001;98(1):53-7. [pmid: 11516800].
Berkkanoglu M, Isikoglu M, Seleker M, et al. Flushing the endometrium prior to the embryo transfer does not affect the pregnancy rate. Reproductive Biomedicine Online. 2006;13(2):268-71. [pmid: 16895645].
Bhattacharya S, Hamilton MP, Shaaban M, et al. Conventional in-vitro fertilisation versus intracytoplasmic sperm injection for the treatment of non-male-factor infertility: a randomised controlled trial. Lancet. 2001;357(9274):2075-9. [pmid: 11445099].
Bjuresten K, Hreinsson JG, Fridstrom M, et al. Embryo transfer by midwife or gynecologist: a prospective randomized study. Acta Obstet Gynecol Scand. 2003;82(5):462-6. [pmid: 12752077].
Boerrigter PJ, de Bie JJ, Mannaerts BM, et al. Obstetrical and neonatal outcome after controlled ovarian stimulation for IVF using the GnRH antagonist ganirelix. Hum Reprod. 2002;17(8):2027-34. [pmid: 12151432].
Bonduelle M, Bergh C, Niklasson A, et al. Medical follow-up study of 5-year-old ICSI children. Reproductive Biomedicine Online. 2004;9(1):91-101. [pmid: 15257828].
Bonduelle M, Liebaers I, Deketelaere V, et al. Neonatal data on a cohort of 2889 infants born after ICSI (1991-1999) and of 2995 infants born after IVF (1983-1999). Hum Reprod. 2002;17(3):671-94. [pmid: 11870121].
Bonduelle M, Wennerholm UB, Loft A, et al. A multi-centre cohort study of the physical health of 5-year-old children conceived after intracytoplasmic sperm injection, in vitro fertilization and natural conception. Hum Reprod. 2005;20(2):413-9. [pmid: 15576393].
Boostanfar R, Jain JK, Mishell DR Jr, et al. A prospective randomized trial comparing clomiphene citrate with tamoxifen citrate for ovulation induction. Fertil Steril. 2001;75(5):1024-6. [pmid: 11334921].
Borm G, Mannaerts B. Treatment with the gonadotrophin-releasing hormone antagonist ganirelix in women undergoing ovarian stimulation with recombinant follicle stimulating hormone is effective, safe and convenient: results of a controlled, randomized, multicentre trial. The European Orgalutran Study Group [erratum appears in Hum Reprod 2000 Aug;15(8):1877]. Hum Reprod. 2000;15(7):1490-8. [pmid: 10875855].
Branigan EF, Estes A. Use of micro-dose human chorionic gonadotropin (hCG) after clomiphene citrate (CC) to complete folliculogenesis in previous CC-resistant anovulation. Am J Obstet Gynecol. 2005;192(6):1890-4. discussion 1894–6. [pmid: 15970844].
Branigan EF, Estes A, Walker K, et al. Thorough sonographic oocyte retrieval during in vitro fertilization produces results similar to ovarian wedge resection in patients with clomiphene citrate-resistant polycystic ovarian syndrome. Am J Obstet Gynecol. 2006;194(6):1696-700. discussion 1700–1. [pmid: 16731088].
Branigan EF, Estes MA. A randomized clinical trial of treatment of clomiphene citrate-resistant anovulation with the use of oral contraceptive pill suppression and repeat clomiphene citrate treatment. Am J Obstet Gynecol. 2003;188(6):1424-8. discussion 1429–30. [pmid: 12824973].
Brinton LA, Kruger Kjaer S, Thomsen BL, et al. Childhood tumor risk after treatment with ovulation-stimulating drugs. Fertil Steril. 2004;81(4):1083-91. [pmid: 15066468].
Brinton LA, Lamb EJ, Moghissi KS, et al. Ovarian cancer risk after the use of ovulation-stimulating drugs. Obstet Gynecol. 2004;103(6):1194-203. [pmid: 15172852].
Brinton LA, Lamb EJ, Moghissi KS, et al. Ovarian cancer risk associated with varying causes of infertility. Fertil Steril. 2004;82(2):405-14. [pmid: 15302291].
Brinton LA, Scoccia B, Moghissi KS, et al. Breast cancer risk associated with ovulation-stimulating drugs. Hum Reprod. 2004;19(9):2005-13. [pmid: 15217997].
Brook N, Khalaf Y, Coomarasamy A, et al. A randomized controlled trial of prophylactic antibiotics (co-amoxiclav) prior to embryo transfer. Hum Reprod. 2006;21(11):2911-5. [pmid: 16832124].
Bruinsma F, Venn A, Lancaster P, et al. Incidence of cancer in children born after in-vitro fertilization. Hum Reprod. 2000;15(3):604-7. [pmid: 10686204].
Buckett WM, Chian RC, Holzer H, et al. Obstetric outcomes and congenital abnormalities after in vitro maturation, in vitro fertilization, and intracytoplasmic sperm injection. Obstet Gynecol. 2007;110(4):885-91. [pmid: 17906024].
Bungum M, Bungum L, Humaidan P, et al. Day 3 versus day 5 embryo transfer: a prospective randomized study. Reproductive Biomedicine Online. 2003;7(1):98-104. [pmid: 12930586].
Burkman RT, Tang MT, Malone KE, et al. Infertility drugs and the risk of breast cancer: findings from the National Institute of Child Health and Human Development Women's Contraceptive and Reproductive Experiences Study. Fertil Steril. 2003;79(4):844-51. [pmid: 12749419].
Cahill DJ, Meadowcroft J, Akande VA, et al. Likelihood of natural conception following treatment by IVF. J Assist Reprod Genet. 2005;22(1112):401-5. [pmid: 16331537].
Cai LY, Izumi S, Koido S, et al. Abnormal placental cord insertion may induce intrauterine growth restriction in IVF-twin pregnancies. Hum Reprod. 2006;21(5):1285-90. [pmid: 16497694].
Cerne A, Bergh C, Borg K, et al. Pre-ovarian block versus paracervical block for oocyte retrieval. Hum Reprod. 2006;21(11):2916-21. [pmid: 16840798].
Cha KY, Wirth DP. Does prayer influence the success of in vitro fertilization-embryo transfer? Report of a masked, randomized trial. J Reprod Med. 2001;46(9):781-7. [pmid: 11584476].
Chakravarty BN, Shirazee HH, Dam P, et al. Oral dydrogesterone versus intravaginal micronised progesterone as luteal phase support in assisted reproductive technology (ART) cycles: results of a randomised study. Journal of Steroid Biochemistry & Molecular Biology. 2005;97(5):416-20. [pmid: 16213136].
Chan CH, Ng EH, Chan CL, et al. Effectiveness of psychosocial group intervention for reducing anxiety in women undergoing in vitro fertilization: a randomized controlled study. Fertil Steril. 2006;85(2):339-46. [pmid: 16595209].
Chang P, Kenley S, Burns T, et al. Recombinant human chorionic gonadotropin (rhCG) in assisted reproductive technology: results of a clinical trial comparing two doses of rhCG (Ovidrel) to urinary hCG (Profasi) for induction of final follicular maturation in in vitro fertilization-embryo transfer. Fertil Steril. 2001;76(1):67-74. [pmid: 11438321].
Cheang CU, Huang LS, Lee TH, et al. A comparison of the outcomes between twin and reduced twin pregnancies produced through assisted reproduction. Fertil Steril. 2007;88(1):47-52. [pmid: 17270181].
Checa MA, Prat M, Robles A, et al. Use of gonadotropin-releasing hormone antagonists to overcome the drawbacks of intrauterine insemination on weekends. Fertil Steril. 2006;85(3):573-7. [pmid: 16500321].
Check JH, Choe JK, Katsoff B, et al. Ectopic pregnancy is not more likely following fresh vs frozen embryo transfer. Clin Exp Obstet Gynecol. 2005;32(2):95-6. [pmid: 16108389].
Check ML, Check JH, Choel JK, et al. Effect of antagonists vs agonists on in vitro fertilization outcome. Clin Exp Obstet Gynecol. 2004;31(4):257-9. [pmid: 15672958].
Chen C, Kattera S. Comparison of pronuclear zygote morphology and early cleavage status of zygotes as additional criteria in the selection of day 3 embryos: a randomized study. Fertil Steril. 2006;85(2):347-52. [pmid: 16595210].
Cheung LP, Lam PM, Lok IH, et al. GnRH antagonist versus long GnRH agonist protocol in poor responders undergoing IVF: a randomized controlled trial. Hum Reprod. 2005;20(3):616-21. [pmid: 15608037].
Child TJ, Henderson AM, Tan SL. The desire for multiple pregnancy in male and female infertility patients. Hum Reprod. 2004;19(3):558-61. [pmid: 14998951].
Choi SJ, Kim HS, Roh CR. Pregnancy outcomes of twins after in vitro and spontaneous fertilization. Int J Gynaecol Obstet. 2006;94(1):49-51. [pmid: 16730009].
Chow JS, Benson CB, Racowsky C, et al. Frequency of a monochorionic pair in multiple gestations: relationship to mode of conception. J Ultrasound Med. 2001;20(7):757-60. quiz 761. [pmid: 11444734].
Christin-Maitre S, Hugues JN. Recombinant FSH Study Group. A comparative randomized multicentric study comparing the step-up versus step-down protocol in polycystic ovary syndrome. Hum Reprod. 2003;18(8):1626-31. [pmid: 12871872].
Chung K, Coutifaris C, Chalian R, et al. Factors influencing adverse perinatal outcomes in pregnancies achieved through use of in vitro fertilization. Fertil Steril. 2006;86(6):1634-41. [pmid: 17074345].
Clayton HB, Schieve LA, Peterson HB, et al. A comparison of heterotopic and intrauterine-only pregnancy outcomes after assisted reproductive technologies in the United States from 1999 to 2002. Fertil Steril. 2007;87(2):303-9. [pmid: 17113092].
Clayton HB, Schieve LA, Peterson HB, et al. Ectopic pregnancy risk with assisted reproductive technology procedures. Obstet Gynecol. 2006;107(3):595-604. [pmid: 16507930].
Coroleu B, Barri PN, Carreras O, et al. Effect of using an echogenic catheter for ultrasound-guided embryo transfer in an IVF programme: a prospective, randomized, controlled study. Hum Reprod. 2006;21(7):1809-15. [pmid: 16556674].
Coroleu B, Barri PN, Carreras O, et al. The usefulness of ultrasound guidance in frozen-thawed embryo transfer: a prospective randomized clinical trial. Hum Reprod. 2002;17(11):2885-90. [pmid: 12407044].
Coroleu B, Carreras O, Veiga A, et al. Embryo transfer under ultrasound guidance improves pregnancy rates after in-vitro fertilization. Hum Reprod. 2000;15(3):616-20. [pmid: 10686207].
Crosignani PG, Somigliana E. Intrauterine Insemination Study Group. Effect of GnRH antagonists in FSH mildly stimulated intrauterine insemination cycles: a multicentre randomized trial. Hum Reprod. 2007;22(2):500-5. [pmid: 17062582].
Cusido M, Fabregas R, Pere BS, et al. Ovulation induction treatment and risk of borderline ovarian tumors. Gynecol Endocrinol. 2007;23(7):373-6. [pmid: 17701767].
da Costa AL AL, Abdelmassih S, de Oliveira FG, et al. Monozygotic twins and transfer at the blastocyst stage after ICSI. Hum Reprod. 2001;16(2):333-6. [pmid: 11157829].
Dal Prato L, Borini A, Cattoli M, et al. Endometrial preparation for frozen-thawed embryo transfer with or without pretreatment with gonadotropin-releasing hormone agonist. Fertil Steril. 2002;77(5):956-60. [pmid: 12009350].
Dal Prato L, Borini A, Coticchio G, et al. Half-dose depot triptorelin in pituitary suppression for multiple ovarian stimulation in assisted reproduction technology: a randomized study. Hum Reprod. 2004;19(10):2200-5. [pmid: 15271868].
Dal Prato L, Borini A, Trevisi MR, et al. Effect of reduced dose of triptorelin at the start of ovarian stimulation on the outcome of IVF: a randomized study. Hum Reprod. 2001;16(7):1409-14. [pmid: 11425821].
Dale B, Fiorentino A, de Simone ML, et al. Zygote versus embryo transfer: a prospective randomized multicenter trial. J Assist Reprod Genet. 2002;19(10):456-61. [pmid: 12416649].
Daniel Y, Ochshorn Y, Fait G, et al. Analysis of 104 twin pregnancies conceived with assisted reproductive technologies and 193 spontaneously conceived twin pregnancies. Fertil Steril. 2000;74(4):683-9. [pmid: 11020507].
Dankert T, Kremer JA, Cohlen BJ, et al. A randomized clinical trial of clomiphene citrate versus low dose recombinant FSH for ovarian hyperstimulation in intrauterine insemination cycles for unexplained and male subfertility. Hum Reprod. 2007;22(3):792-7. [pmid: 17110396].
de Boer EJ, den Tonkelaar I, Burger CW, et al. Are cause of subfertility and in vitro fertilization treatment risk factors for an earlier start of menopause?. Menopause. 2005;12(5):578-88. [pmid: 16145312].
de Camargo Martins AM, Baruffi RL, Mauri AL, et al. Ultrasound guidance is not necessary during easy embryo transfers. J Assist Reprod Genet. 2004;21(12):421-5. [pmid: 15704516].
De Neubourg D, Gerris J, Mangelschots K, et al. The obstetrical and neonatal outcome of babies born after single-embryo transfer in IVF/ICSI compares favourably to spontaneously conceived babies. Hum Reprod. 2006;21(4):1041-6. [pmid: 16428333].
De Neubourg D, Mangelschots K, Van Royen E, et al. Singleton pregnancies are as affected by ovarian hyperstimulation syndrome as twin pregnancies. Fertil Steril. 2004;82(6):1691-3. [pmid: 15589884].
De Placido G, Alviggi C, Perino A, et al. Recombinant human LH supplementation versus recombinant human FSH (rFSH) step-up protocol during controlled ovarian stimulation in normogonadotrophic women with initial inadequate ovarian response to rFSH. A multicentre, prospective, randomized controlled trial. Hum Reprod. 2005;20(2):390-6. [pmid: 15576390].
De Placido G, Mollo A, Alviggi C, et al. Rescue of IVF cycles by HMG in pituitary down-regulated normogonadotrophic young women characterized by a poor initial response to recombinant FSH. Hum Reprod. 2001;16(9):1875-9. [pmid: 11527891].
De Placido G, Mollo A, Clarizia R, et al. Gonadotropin-releasing hormone (GnRH) antagonist plus recombinant luteinizing hormone vs. a standard GnRH agonist short protocol in patients at risk for poor ovarian response. Fertil Steril. 2006;85(1):247-50. [pmid: 16412769].
De Sutter P, Delbaere I, Gerris J, et al. Birthweight of singletons after assisted reproduction is higher after single- than after double-embryo transfer. Hum Reprod. 2006;21(10):2633-7. [pmid: 16785258].
De Sutter P, Veldeman L, Kok P, et al. Comparison of outcome of pregnancy after intra-uterine insemination (IUI) and IVF. Hum Reprod. 2005;20(6):1642-6. [pmid: 15790611].
Dehbashi S, Vafaei H, Parsanezhad MD, et al. Time of initiation of clomiphene citrate and pregnancy rate in polycystic ovarian syndrome. Int J Gynaecol Obstet. 2006;93(1):44-8. [pmid: 16530767].
Demirol A, Gurgan T. Comparison of different gonadotrophin preparations in intrauterine insemination cycles for the treatment of unexplained infertility: a prospective, randomized study. Hum Reprod. 2007;22(1):97-100. [pmid: 16954409].
Demirol A, Guven S, Baykal C, et al. Effect of endometrioma cystectomy on IVF outcome: a prospective randomized study. Reproductive Biomedicine Online. 2006;12(5):639-43. [pmid: 16790114].
Derom C, Leroy F, Vlietinck R, et al. High frequency of iatrogenic monozygotic twins with administration of clomiphene citrate and a change in chorionicity. Fertil Steril. 2006;85(3):755-7. [pmid: 16500356].
Devroey P, Fauser BC, Platteau P, et al. Induction of multiple follicular development by a single dose of long-acting recombinant follicle-Stimulating hormone (FSH-CTP, corifollitropin alfa) for controlled ovarian stimulation before in vitro fertilization. J Clin Endocrinol Metab. 2004;89(5):2062-70. [pmid: 15126522].
Dickey RP, Nichols JE, Steinkampf MP, et al. Highly purified human-derived follicle-stimulating hormone (Bravelle) has equivalent efficacy to follitropin-beta (Follistim) in infertile women undergoing in vitro fertilization. Reproductive Biology & Endocrinology. 2003;1(1):63. [pmid: 14609434]. [pmcid: 270000].
Dieterle S, Ying G, Hatzmann W, et al. Effect of acupuncture on the outcome of in vitro fertilization and intracytoplasmic sperm injection: a randomized, prospective, controlled clinical study. Fertil Steril. 2006;85(5):1347-51. [pmid: 16616748].
Dokras A, Baredziak L, Blaine J, et al. Obstetric outcomes after in vitro fertilization in obese and morbidly obese women. Obstet Gynecol. 2006;108(1):61-9. [pmid: 16816057].
Dor J, Bider D, Shulman A, et al. Effects of gonadotrophin-releasing hormone agonists on human ovarian steroid secretion in vivo and in vitro-results of a prospective, randomized in-vitro fertilization study. Hum Reprod. 2000;15(6):1225-30. [pmid: 10831545].
Dor J, Lerner-Geva L, Rabinovici J, et al. Cancer incidence in a cohort of infertile women who underwent in vitro fertilization. Fertil Steril. 2002;77(2):324-7. [pmid: 11821091].
Doria-Rose VP, Lou Biggs M, Weiss NS. Subfertility and the risk of testicular germ cell tumors (United States). Cancer Causes & Control. 2005;16(6):651-6. [pmid: 16049803].
Drakakis P, Loutradis D, Kallianidis K, et al. Small doses of LH activity are needed early in ovarian stimulation for better quality oocytes in IVF-ET. Eur J Obstet Gynecol Reprod Biol. 2005;121(1):77-80. [pmid: 15989987].
Driscoll GL, Tyler JP, Hangan JT, et al. A prospective, randomized, controlled, double-blind, double-dummy comparison of recombinant and urinary HCG for inducing oocyte maturation and follicular luteinization in ovarian stimulation. Hum Reprod. 2000;15(6):1305-10. [pmid: 10831560].
Duvan CI, Ozmen B, Satiroglu H, et al. Does addition of low-dose aspirin and/or steroid as a standard treatment in nonselected intracytoplasmic sperm injection cycles improve in vitro fertilization success? A randomized, prospective, placebo-controlled study. J Assist Reprod Genet. 2006;23(1):15-21. [pmid: 16518579].
El Hage S, Ghanem I, Safi CA, et al. The risk of neuro-orthopaedic malformations following in-vitro fertilization. Journal of Pediatric Orthopaedics, Part B. 2006;15(3):229-32.
El-Toukhy T, Taylor A, Khalaf Y, et al. Pituitary suppression in ultrasound-monitored frozen embryo replacement cycles. A randomised study. Hum Reprod. 2004;19(4):874-9. [pmid: 15016780].
Ellison MA, Hotamisligil S, Lee H, et al. Psychosocial risks associated with multiple births resulting from assisted reproduction. Fertil Steril. 2005;83(5):1422-8. [pmid: 15866579].
Elnashar A, Abdelmageed E, Fayed M, et al. Clomiphene citrate and dexamethazone in treatment of clomiphene citrate-resistant polycystic ovary syndrome: a prospective placebo-controlled study. Hum Reprod. 2006;21(7):1805-8. [pmid: 16543255].
Emiliani S, Fasano G, Vandamme B, et al. Impact of the assessment of early cleavage in a single embryo transfer policy. Reproductive Biomedicine Online. 2006;13(2):255-60. [pmid: 16895641].
Engmann L, DiLuigi A, Schmidt D, et al. The use of gonadotropin-releasing hormone (GnRH) agonist to induce oocyte maturation after cotreatment with GnRH antagonist in high-risk patients undergoing in vitro fertilization prevents the risk of ovarian hyperstimulation syndrome: a prospective randomized controlled study. Fertil Steril. 2008;89(1):84-91. [pmid: 17462639].
Erez O, Vardi IS, Hallak M, et al. Preeclampsia in twin gestations: association with IVF treatments, parity and maternal age. Journal of Maternal-Fetal & Neonatal Medicine. 2006;19(3):141-6. [pmid: 16690506].
Ericson A, Nygren KG, Olausson PO, et al. Hospital care utilization of infants born after IVF. Hum Reprod. 2002;17(4):929-32. [pmid: 11925384].
Escudero E, Bosch E, Crespo J, et al. Comparison of two different starting multiple dose gonadotropin-releasing hormone antagonist protocols in a selected group of in vitro fertilization-embryo transfer patients. Fertil Steril. 2004;81(3):562-6. [pmid: 15037403].
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone. Efficacy and safety of highly purified menotropin versus recombinant follicle-stimulating hormone in in vitro fertilization/intracytoplasmic sperm injection cycles: a randomized, comparative trial. Fertil Steril. 2002;78(3):520–8.
European and Middle East Orgalutran Study Group. Comparable clinical outcome using the GnRH antagonist ganirelix or a long protocol of the GnRH agonist triptorelin for the prevention of premature LH surges in women undergoing ovarian stimulation. Hum Reprod. 2001;16(4):644-51. [pmid: 11278211].
European Recombinant Human Chorionic Gonadotrophin Study Group. Induction of final follicular maturation and early luteinization in women undergoing ovulation induction for assisted reproduction treatment—recombinant HCG versus urinary HCG. The European Recombinant Human Chorionic Gonadotrophin Study Group. Hum Reprod. 2000;15(7):1446-51. [pmid: 10875887].
European Recombinant LH Study Group. Human recombinant luteinizing hormone is as effective as, but safer than, urinary human chorionic gonadotropin in inducing final follicular maturation and ovulation in in vitro fertilization procedures: results of a multicenter double-blind study. J Clin Endocrinol Metab. 2001;86(6):2607-18. [pmid: 11397861].
Fabregues F, Creus M, Penarrubia J, et al. Effects of recombinant human luteinizing hormone supplementation on ovarian stimulation and the implantation rate in down-regulated women of advanced reproductive age. Fertil Steril. 2006;85(4):925-31. [pmid: 16580376].
Fabregues F, Penarrubia J, Creus M, et al. Effect of halving the daily dose of triptorelin at the start of ovarian stimulation on hormone serum levels and the outcome of in vitro fertilization. Fertil Steril. 2005;83(3):785-8. [pmid: 15749520].
Fancsovits P, Toth L, Murber A, et al. Catheter type does not affect the outcome of intrauterine insemination treatment: a prospective randomized study. Fertil Steril. 2005;83(3):699-704. [pmid: 15749500].
Farquhar CM, Williamson K, Gudex G, et al. A randomized controlled trial of laparoscopic ovarian diathermy versus gonadotropin therapy for women with clomiphene citrate-resistant polycystic ovary syndrome. Fertil Steril. 2002;78(2):404-11. [pmid: 12137881].
Farr SL, Schieve LA, Jamieson DJ. Pregnancy loss among pregnancies conceived through assisted reproductive technology, United States, 1999-2002. Am J Epidemiol. 2007;165(12):1380-8. [pmid: 17351291].
Fatemi HM, Kolibianakis E, Tournaye H, et al. Clomiphene citrate versus letrozole for ovarian stimulation: a pilot study. Reproductive Biomedicine Online. 2003;7(5):543-6. [pmid: 14680546].
Fatemi HM, Kolibianakis EM, Camus M, et al. Addition of estradiol to progesterone for luteal supplementation in patients stimulated with GnRH antagonist/rFSH for IVF: a randomized controlled trial. Hum Reprod. 2006;21(10):2628-32. [pmid: 16857887].
Filicori M, Cognigni GE, Pocognoli P, et al. Comparison of controlled ovarian stimulation with human menopausal gonadotropin or recombinant follicle-stimulating hormone. Fertil Steril. 2003;80(2):390-7. [pmid: 12909504].
Fisher JR, Hammarberg K, Baker HW. Assisted conception is a risk factor for postnatal mood disturbance and early parenting difficulties. Fertil Steril. 2005;84(2):426-30. [pmid: 16084885].
Fleming R, Hopkinson ZE, Wallace AM, et al. Ovarian function and metabolic factors in women with oligomenorrhea treated with metformin in a randomized double blind placebo-controlled trial. J Clin Endocrinol Metab. 2002;87(2):569-74. [pmid: 11836287].
Fluker M, Grifo J, Leader A, et al. Efficacy and safety of ganirelix acetate versus leuprolide acetate in women undergoing controlled ovarian hyperstimulation. Fertil Steril. 2001;75(1):38-45. [pmid: 11163814].
Foong SC, Fleetham JA, O'Keane JA, et al. A prospective randomized trial of conventional in vitro fertilization versus intracytoplasmic sperm injection in unexplained infertility. J Assist Reprod Genet. 2006;23(3):137-40. [pmid: 16622804].
Friedler S, Schachter M, Strassburger D, et al. A randomized clinical trial comparing recombinant hyaluronan/recombinant albumin versus human tubal fluid for cleavage stage embryo transfer in patients with multiple IVF-embryo transfer failure. Hum Reprod. 2007;22(9):2444-8. [pmid: 17644629].
Frydman N, Madoux S, Hesters L, et al. A randomized double-blind controlled study on the efficacy of laser zona pellucida thinning on live birth rates in cases of advanced female age. Hum Reprod. 2006;21(8):2131-5. [pmid: 16644913].
Frydman R, Howles CM, Truong F. A double-blind, randomized study to compare recombinant human follicle stimulating hormone (FSH; Gonal-F) with highly purified urinary FSH (Metrodin) HP) in women undergoing assisted reproductive techniques including intracytoplasmic sperm injection. The French Multicentre Trialists. Hum Reprod. 2000;15(3):520-5. [pmid: 10686190].
Fujimoto A, Osuga Y, Fujiwara T, et al. Human chorionic gonadotropin combined with progesterone for luteal support improves pregnancy rate in patients with low late-midluteal estradiol levels in IVF cycles. J Assist Reprod Genet. 2002;19(12):550-4. [pmid: 12503886].
Garcia-Velasco JA, Isaza V, Requena A, et al. High doses of gonadotrophins combined with stop versus non-stop protocol of GnRH analogue administration in low responder IVF patients: a prospective, randomized, controlled trial. Hum Reprod. 2000;15(11):2292-6. [pmid: 11056121].
Gardner DK, Surrey E, Minjarez D, et al. Single blastocyst transfer: a prospective randomized trial. Fertil Steril. 2004;81(3):551-5. [pmid: 15037401].
Gauthier E, Paoletti X, Clavel-Chapelon F, et al. Breast cancer risk associated with being treated for infertility: results from the French E3N cohort study. Hum Reprod. 2004;19(10):2216-21. [pmid: 15271872].
Geber S, Moreira AC, de Paula SO, et al. Comparison between two forms of vaginally administered progesterone for luteal phase support in assisted reproduction cycles. Reproductive Biomedicine Online. 2007;14(2):155-8. [pmid: 17298716].
Geipel A, Ludwig M, Germer U, et al. Uterine artery Doppler velocimetry and the outcome of pregnancies resulting from ICSI. Hum Reprod. 2001;16(7):1397-402. [pmid: 11425819].
George K, George S, Chandy A, et al. hCG administration offers no outcome benefit over spontaneous ovulation in anovulatory women treated with clomiphene citrate. Fertil Steril. 2007;87(4):985-7. [pmid: 17239866].
George SS, George K, Irwin C, et al. Sequential treatment of metformin and clomiphene citrate in clomiphene-resistant women with polycystic ovary syndrome: a randomized, controlled trial. Hum Reprod. 2003;18(2):299-304. [pmid: 12571165].
Gerli S, Casini ML, Unfer V, et al. Ovulation induction with urinary FSH or recombinant FSH in polycystic ovary syndrome patients: a prospective randomized analysis of cost-effectiveness. Reproductive Biomedicine Online. 2004;9(5):494-9. [pmid: 15588465].
Gerli S, Gholami H, Manna C, et al. Use of ethinyl estradiol to reverse the antiestrogenic effects of clomiphene citrate in patients undergoing intrauterine insemination: a comparative, randomized study. Fertil Steril. 2000;73(1):85-9. [pmid: 10632418].
Ghazeeri G, Kutteh WH, Bryer-Ash M, et al. Effect of rosiglitazone on spontaneous and clomiphene citrate-induced ovulation in women with polycystic ovary syndrome. Fertil Steril. 2003;79(3):562-6. [pmid: 12620440].
Glazebrook C, Sheard C, Cox S, et al. Parenting stress in first-time mothers of twins and triplets conceived after in vitro fertilization. Fertil Steril. 2004;81(3):505-11. [pmid: 15037391].
Gokmen O, Ugur M, Ekin M, et al. Intravenous albumin versus hydroxyethyl starch for the prevention of ovarian hyperstimulation in an in-vitro fertilization programme: a prospective randomized placebo controlled study. Eur J Obstet Gynecol Reprod Biol. 2001;96(2):187-92. [pmid: 11384805].
Gomes MK, Vieira CS, Moura MD, et al. Controlled ovarian stimulation with exclusive FSH followed by stimulation with hCG alone, FSH alone or hMG. Eur J Obstet Gynecol Reprod Biol. 2007;130(1):99-106. [pmid: 16835006].
Gomez-Palomares JL, Acevedo-Martin B, Andres L, et al. LH improves early follicular recruitment in women over 38 years old [erratum appears in Reprod Biomed Online. 2006 Jan;12(1):132]. Reproductive Biomedicine Online. 2005;11(4):409-14. [pmid: 16274596].
Gomez-Palomares JL, Julia B, Acevedo-Martin B, et al. Timing ovulation for intrauterine insemination with a GnRH antagonist. Hum Reprod. 2005;20(2):368-72. [pmid: 15567879].
Goody A, Rice F, Boivin J, et al. Twins born following fertility treatment: implications for quantitative genetic studies. Twin Research & Human Genetics: the Official Journal of the International Society for Twin Studies. 2005;8(4):337-45. [pmid: 16176718].
Gordon UD, Harrison RF, Fawzy M, et al. A randomized prospective assessor-blind evaluation of luteinizing hormone dosage and in vitro fertilization outcome. Fertil Steril. 2001;75(2):324-31. [pmid: 11172834].
Goswami SK, Das T, Chattopadhyay R, et al. A randomized single-blind controlled trial of letrozole as a low-cost IVF protocol in women with poor ovarian response: a preliminary report. Hum Reprod. 2004;19(9):2031-5. [pmid: 15217999].
Goverde AJ, McDonnell J, Vermeiden JP, et al. Intrauterine insemination or in-vitro fertilisation in idiopathic subfertility and male subfertility: a randomised trial and cost-effectiveness analysis. Lancet. 2000;355(9197):13-8. [pmid: 10615885].
Gray RH, Wu LY. Subfertility and risk of spontaneous abortion. Am J Public Health. 2000;90(9):1452-4. [pmid: 10983206]. [pmcid: 1447624].
Greco E, Polonio-Balbi P, Ferrero S, et al. Use of a fully automated injector for self-administration of follitropin alpha in an IVF/ICSI programme. Reproductive Biomedicine Online. 2005;11(4):415-20. [pmid: 16274597].
Griesinger G, Schultze-Mosgau A, Dafopoulos K, et al. Recombinant luteinizing hormone supplementation to recombinant follicle-stimulating hormone induced ovarian hyperstimulation in the GnRH-antagonist multiple-dose protocol. Hum Reprod. 2005;20(5):1200-6. [pmid: 15665010].
Grigoriou O, Makrakis E, Konidaris S, et al. Effect of sperm treatment with exogenous platelet-activating factor on the outcome of intrauterine insemination. Fertil Steril. 2005;83(3):618-21. [pmid: 15749490].
Hansen M, Kurinczuk JJ, Bower C, et al. The risk of major birth defects after intracytoplasmic sperm injection and in vitro fertilization. N Engl J Med. 2002;346(10):725-30. [pmid: 11882727].
Hashimoto LN, Lindsell CJ, Brewer DE, et al. Contributions of infertility treatment to very-low-birth-weight multiple birth infants receiving neonatal intensive care. Am J Obstet Gynecol. 2004;190(2):401-6. [pmid: 14981381].
Hassan HA, Azab H, Rahman AA, et al. Effects of growth hormone on in vitro maturation of germinal vesicle of human oocytes retrieved from small antral follicles. J Assist Reprod Genet. 2001;18(8):417-20. [pmid: 11599461].
Heijnen EM, Eijkemans MJ, De Klerk C, et al. A mild treatment strategy for in-vitro fertilisation: a randomised non-inferiority trial. Lancet. 2007;369(9563):743-9. [pmid: 17336650].
Heijnen EM, Klinkert ER, Schmoutziguer AP, et al. Prevention of multiple pregnancies after IVF in women 38 and older: a randomized study. Reproductive Biomedicine Online. 2006;13(3):386-93. [pmid: 16984771].
Hernandez-Diaz S, Werler MM, Mitchell AA. Gestational hypertension in pregnancies supported by infertility treatments: role of infertility, treatments, and multiple gestations. Fertil Steril. 2007;88(2):438-45. [pmid: 17449034].
Hjelmstedt A, Widstrom AM, Wramsby H, et al. Personality factors and emotional responses to pregnancy among IVF couples in early pregnancy: a comparative study. Acta Obstet Gynecol Scand. 2003;82(2):152-61. [pmid: 12648178].
Hohmann FP, Macklon NS, Fauser BC. A randomized comparison of two ovarian stimulation protocols with gonadotropin-releasing hormone (GnRH) antagonist cotreatment for in vitro fertilization commencing recombinant follicle-stimulating hormone on cycle day 2 or 5 with the standard long GnRH agonist protocol. J Clin Endocrinol Metab. 2003;88(1):166-73. [pmid: 12519847].
Hoomans EH, Mulder BB. Asian Purgeon Study Group. A group-comparative, randomized, double-blind comparison of the efficacy and efficiency of two fixed daily dose regimens (100- and 200-IU) of recombinant follicle stimulating hormone (rFSH, Puregon) in Asian women undergoing ovarian stimulation for IVF/ICSI. J Assist Reprod Genet. 2002;19(10):470-6. [pmid: 12416651].
Hourvitz A, Pri-Paz S, Dor J, et al. Neonatal and obstetric outcome of pregnancies conceived by ICSI or IVF. Reproductive Biomedicine Online. 2005;11(4):469-75. [pmid: 16274611].
Hreinsson J, Rosenlund B, Friden B, et al. Recombinant LH is equally effective as recombinant hCG in promoting oocyte maturation in a clinical in-vitro maturation programme: a randomized study. Hum Reprod. 2003;18(10):2131-6. [pmid: 14507834].
Hreinsson J, Rosenlund B, Fridstrom M, et al. Embryo transfer is equally effective at cleavage stage and blastocyst stage: a randomized prospective study. Eur J Obstet Gynecol Reprod Biol. 2004;117(2):194-200. [pmid: 15541857].
Hsieh YY, Tsai HD, Chang FC. Routine blastocyst culture and transfer: 201 patients' experience. J Assist Reprod Genet. 2000;17(8):405-8. [pmid: 11062848].
Huang CT, Au HK, Chien LW, et al. Twin pregnancy outcome among cases of spontaneous conception, intrauterine insemination, and in vitro fertilization/intracytoplasmic sperm injection. Fertil Steril. 2006;86(4):1017-9. [pmid: 16963039].
Hughes EG, Beecroft ML, Wilkie V, et al. A multicentre randomized controlled trial of expectant management versus IVF in women with Fallopian tube patency. Hum Reprod. 2004;19(5):1105-9. [pmid: 15044399].
Hugues JN, Barlow DH, Rosenwaks Z, et al. Improvement in consistency of response to ovarian stimulation with recombinant human follicle stimulating hormone resulting from a new method for calibrating the therapeutic preparation. Reproductive Biomedicine Online. 2003;6(2):185-90. [pmid: 12675998].
Hui PW, Lam YH, Tang MH, et al. Maternal serum pregnancy-associated plasma protein-A and free beta-human chorionic gonadotrophin in pregnancies conceived with fresh and frozen-thawed embryos from in vitro fertilization and intracytoplasmic sperm injection. Prenat Diagn. 2005;25(5):390-3. [pmid: 15906430].
Hui PW, Tang MH, Lam YH, et al. Nuchal translucency in pregnancies conceived after assisted reproduction technology. Ultrasound Obstet Gynecol. 2005;25(3):234-8. [pmid: 15736183].
Hui PW, Tang MH, Ng EH, et al. Nuchal translucency in dichorionic twins conceived after assisted reproduction. Prenat Diagn. 2006;26(6):510-3. [pmid: 16639691].
Huirne JA, van Loenen AC, Donnez J, et al. Effect of an oral contraceptive pill on follicular development in IVF/ICSI patients receiving a GnRH antagonist: a randomized study. Reproductive Biomedicine Online. 2006;13(2):235-45. [pmid: 16895639].
Humaidan P, Bredkjaer HE, Bungum L, et al. GnRH agonist (buserelin) or hCG for ovulation induction in GnRH antagonist IVF/ICSI cycles: a prospective randomized study. Hum Reprod. 2005;20(5):1213-20. [pmid: 15760966].
Humaidan P, Brock K, Bungum L, et al. Pain relief during oocyte retrieval—exploring the role of different frequencies of electro-acupuncture. Reproductive Biomedicine Online. 2006;13(1):120-5. [pmid: 16820123].
Humaidan P, Bungum L, Bungum M, et al. Rescue of corpus luteum function with peri-ovulatory HCG supplementation in IVF/ICSI GnRH antagonist cycles in which ovulation was triggered with a GnRH agonist: a pilot study. Reproductive Biomedicine Online. 2006;13(2):173-8. [pmid: 16895629].
Humaidan P, Bungum M, Bungum L, et al. Effects of recombinant LH supplementation in women undergoing assisted reproduction with GnRH agonist down-regulation and stimulation with recombinant FSH: an opening study. Reproductive Biomedicine Online. 2004;8(6):635-43. [pmid: 15169576].
Humaidan P, Stener-Victorin E. Pain relief during oocyte retrieval with a new short duration electro-acupuncture technique—an alternative to conventional analgesic methods. Hum Reprod. 2004;19(6):1367-72. [pmid: 15105387].
Hvidtjorn D, Grove J, Schendel D, et al. ‘Vanishing embryo syndrome’ in IVF/ICSI. Hum Reprod. 2005;20(9):2550-1. [pmid: 15890728].
Hvidtjorn D, Grove J, Schendel DE, et al. Cerebral palsy among children born after in vitro fertilization: the role of preterm delivery—a population-based, cohort study. Pediatrics. 2006;118(2):475-82. [pmid: 16882798].
Hwang JL, Seow KM, Lin YH, et al. Ovarian stimulation by concomitant administration of cetrorelix acetate and HMG following Diane-35 pre-treatment for patients with polycystic ovary syndrome: a prospective randomized study. Hum Reprod. 2004;19(9):1993-2000. [pmid: 15284212].
Ingerslev HJ, Hojgaard A, Hindkjaer J, et al. A randomized study comparing IVF in the unstimulated cycle with IVF following clomiphene citrate. Hum Reprod. 2001;16(4):696-702. [pmid: 11278221].
International Recombinant Human Chorionic Gonadotropin Study Group. Induction of ovulation in World Health Organization group II anovulatory women undergoing follicular stimulation with recombinant human follicle-stimulating hormone: a comparison of recombinant human chorionic gonadotropin (rhCG) and urinary hCG. Fertil Steril. 2001;75(6):1111-8. [pmid: 11384635].
Isaksson R, Gissler M, Tiitinen A. Obstetric outcome among women with unexplained infertility after IVF: a matched case-control study. Hum Reprod. 2002;17(7):1755-61. [pmid: 12093835].
Isik AZ, Vicdan K, Kaba A, et al. Comparison of zona manipulated and zona intact blastocyst transfers: a prospective randomized trial. J Assist Reprod Genet. 2000;17(3):135-9. [pmid: 10911572].
Isikoglu M, Ozgur K, Oehninger S. Extension of GnRH agonist through the luteal phase to improve the outcome of intracytoplasmic sperm injection. J Reprod Med. 2007;52(7):639-44. [pmid: 17847764].
Jaroudi K, Al-Hassan S, Sieck U, et al. Zygote transfer on day 1 versus cleavage stage embryo transfer on day 3: a prospective randomized trial. Hum Reprod. 2004;19(3):645-8. [pmid: 14998964].
Jelinkova L, Pavelkova J, Strehler E, et al. Improved implantation rate after chemical removal of the zona pellucida. Fertil Steril. 2003;79(6):1299-303. [pmid: 12798874].
Jensen A, Sharif H, Svare EI, et al. Risk of breast cancer after exposure to fertility drugs: results from a large Danish cohort study. Cancer Epidemiol Biomarkers Prev. 2007;16(7):1400-7. [pmid: 17585058].
Jun SH, Milki AA. Assisted hatching is associated with a higher ectopic pregnancy rate. Fertil Steril. 2004;81(6):1701-3. [pmid: 15193502].
Jun SH, Milki AA. Ectopic pregnancy rates with frozen compared with fresh blastocyst transfer. Fertil Steril. 2007;88(3):629-31. [pmid: 17434510].
Kallen B, Finnstrom O, Nygren KG, et al. In vitro fertilization (IVF) in Sweden: risk for congenital malformations after different IVF methods. Birth Defects Research. 2005;73(3):162-9. [pmid: 15678490].
Kallen B, Robert-Gnansia E. Maternal drug use, fertility problems, and infant craniostenosis. Cleft Palate Craniofac J. 2005;42(6):589-93. [pmid: 16241169].
Kanyo K, Konc J. A follow-up study of children born after diode laser assisted hatching. Eur J Obstet Gynecol Reprod Biol. 2003;110(2):176-80. [pmid: 12969579].
Karaki RZ, Samarraie SS, Younis NA, et al. Blastocyst culture and transfer: a step toward improved in vitro fertilization outcome. Fertil Steril. 2002;77(1):114-8. [pmid: 11779600].
Karlstrom PO, Bergh T, Lundkvist O. Addition of gonadotrophin-releasing hormone agonist and/or two inseminations with husband's sperm do not improve the pregnancy rate in superovulated cycles. Acta Obstet Gynecol Scand. 2000;79(1):37-42. [pmid: 10646814].
Katalinic A, Rosch C, Ludwig M, et al. Pregnancy course and outcome after intracytoplasmic sperm injection: a controlled, prospective cohort study. Fertil Steril. 2004;81(6):1604-16. [pmid: 15193484].
Kattera S, Chen C. Short coincubation of gametes in in vitro fertilization improves implantation and pregnancy rates: a prospective, randomized, controlled study. Fertil Steril. 2003;80(4):1017-21. [pmid: 14556826].
Keay SD, Lenton EA, Cooke ID, et al. Low-dose dexamethasone augments the ovarian response to exogenous gonadotrophins leading to a reduction in cycle cancellation rate in a standard IVF programme. Hum Reprod. 2001;16(9):1861-5. [pmid: 11527889].
Kilani Z, Dakkak A, Ghunaim S, et al. A prospective, randomized, controlled trial comparing highly purified hMG with recombinant FSH in women undergoing ICSI: ovarian response and clinical outcomes. Hum Reprod. 2003;18(6):1194-9. [pmid: 12773445].
Kjotrod SB, von During V, Carlsen SM. Metformin treatment before IVF/ICSI in women with polycystic ovary syndrome; a prospective, randomized, double blind study. Hum Reprod. 2004;19(6):1315-22. [pmid: 15117902].
Kleinstein J. Luteal Phase Study Group. Efficacy and tolerability of vaginal progesterone capsules (Utrogest 200) compared with progesterone gel (Crinone 8%) for luteal phase support during assisted reproduction. Fertil Steril. 2005;83(6):1641-9. [pmid: 15950631].
Klemetti R, Gissler M, Hemminki E. Comparison of perinatal health of children born from IVF in Finland in the early and late 1990s. Hum Reprod. 2002;17(8):2192-8. [pmid: 12151458].
Klemetti R, Gissler M, Sevon T, et al. Children born after assisted fertilization have an increased rate of major congenital anomalies. Fertil Steril. 2005;84(5):1300-7. [pmid: 16275218].
Klinkert ER, Broekmans FJ, Looman CW, et al. Expected poor responders on the basis of an antral follicle count do not benefit from a higher starting dose of gonadotrophins in IVF treatment: a randomized controlled trial. Hum Reprod. 2005;20(3):611-5. [pmid: 15591079].
Klip H, Burger CW, de Kraker J, et al. Risk of cancer in the offspring of women who underwent ovarian stimulation for IVF. Hum Reprod. 2001;16(11):2451-8. [pmid: 11679537].
Kocak M, Caliskan E, Simsir C, et al. Metformin therapy improves ovulatory rates, cervical scores, and pregnancy rates in clomiphene citrate-resistant women with polycystic ovary syndrome. Fertil Steril. 2002;77(1):101-6. [pmid: 11779598].
Koichi K, Yukiko N, Shima K, et al. Efficacy of low-dose human chorionic gonadotropin (hCG) in a GnRH antagonist protocol. J Assist Reprod Genet. 2006;23(5):223-8. [pmid: 16786420].
Koivurova S, Hartikainen AL, Gissler M, et al. Neonatal outcome and congenital malformations in children born after in-vitro fertilization. Hum Reprod. 2002;17(5):1391-8. [pmid: 11980770].
Koivurova S, Hartikainen AL, Karinen L, et al. The course of pregnancy and delivery and the use of maternal healthcare services after standard IVF in Northern Finland 1990-1995. Hum Reprod. 2002;17(11):2897-903. [pmid: 12407046].
Kolibianakis E, Osmanagaoglu K, De Catte L, et al. Prenatal genetic testing by amniocentesis appears to result in a lower risk of fetal loss than chorionic villus sampling in singleton pregnancies achieved by intracytoplasmic sperm injection. Fertil Steril. 2003;79(2):374-8. [pmid: 12568848].
Kolibianakis EM, Albano C, Camus M, et al. Initiation of gonadotropin-releasing hormone antagonist on day 1 as compared to day 6 of stimulation: effect on hormonal levels and follicular development in in vitro fertilization cycles. J Clin Endocrinol Metab. 2003;88(12):5632-7. [pmid: 14671145].
Kolibianakis EM, Albano C, Camus M, et al. Prolongation of the follicular phase in in vitro fertilization results in a lower ongoing pregnancy rate in cycles stimulated with recombinant follicle-stimulating hormone and gonadotropin-releasing hormone antagonists. Fertil Steril. 2004;82(1):102-7. [pmid: 15236997].
Kolibianakis EM, Papanikolaou EG, Camus M, et al. Effect of oral contraceptive pill pretreatment on ongoing pregnancy rates in patients stimulated with GnRH antagonists and recombinant FSH for IVF. A randomized controlled trial. Hum Reprod. 2006;21(2):352-7. [pmid: 16269449].
Kolibianakis EM, Schultze-Mosgau A, Schroer A, et al. A lower ongoing pregnancy rate can be expected when GnRH agonist is used for triggering final oocyte maturation instead of HCG in patients undergoing IVF with GnRH antagonists. Hum Reprod. 2005;20(10):2887-92. [pmid: 15979994].
Kolibianakis EM, Zikopoulos K, Verpoest W, et al. Should we advise patients undergoing IVF to start a cycle leading to a day 3 or a day 5 transfer?. Hum Reprod. 2004;19(11):2550-4. [pmid: 15298978].
Kontoravdis A, Makrakis E, Pantos K, et al. Proximal tubal occlusion and salpingectomy result in similar improvement in in vitro fertilization outcome in patients with hydrosalpinx. Fertil Steril. 2006;86(6):1642-9. [pmid: 17069813].
Korosec S, Virant-Klun I, Tomazevic T, et al. Single fresh and frozen-thawed blastocyst transfer using hyaluronan-rich transfer medium. Reproductive Biomedicine Online. 2007;15(6):701-7. [pmid: 18062869].
Kosmas IP, Janssens R, De Munck L, et al. Ultrasound-guided embryo transfer does not offer any benefit in clinical outcome: a randomized controlled trial. Hum Reprod. 2007;22(5):1327-34. [pmid: 17289683].
Koudstaal J, Braat DD, Bruinse HW, et al. Obstetric outcome of singleton pregnancies after IVF: a matched control study in four Dutch university hospitals. Hum Reprod. 2000;15(8):1819-25. [pmid: 10920110].
Koudstaal J, Bruinse HW, Helmerhorst FM, et al. Obstetric outcome of twin pregnancies after in-vitro fertilization: a matched control study in four Dutch university hospitals. Hum Reprod. 2000;15(4):935-40. [pmid: 10739845].
Kozinszky Z, Zadori J, Orvos H, et al. Obstetric and neonatal risk of pregnancies after assisted reproductive technology: a matched control study. Acta Obstet Gynecol Scand. 2003;82(9):850-6. [pmid: 12911448].
Kozinszky Z, Zadori J, Orvos H, et al. Risk of cesarean section in singleton pregnancies after assisted reproductive techniques. J Reprod Med. 2003;48(3):160-4. [pmid: 12698772].
Kristiansson P, Bjor O, Wramsby H. Tumour incidence in Swedish women who gave birth following IVF treatment. Hum Reprod. 2007;22(2):421-6. [pmid: 17071821].
Kuwata T, Matsubara S, Ohkuchi A, et al. The risk of birth defects in dichorionic twins conceived by assisted reproductive technology. Twin Research. 2004;7(3):223-7. [pmid: 15193165].
La Sala GB, Nucera G, Gallinelli A, et al. Spontaneous embryonic loss after in vitro fertilization with and without intracytoplasmic sperm injection. Fertil Steril. 2004;82(6):1536-9. [pmid: 15589856].
La Sala GB, Nucera G, Gallinelli A, et al. Spontaneous embryonic loss following in vitro fertilization: incidence and effect on outcomes. Am J Obstet Gynecol. 2004;191(3):741-6. [pmid: 15467533].
Lambert-Messerlian G, Dugoff L, Vidaver J, et al. First- and second-trimester Down syndrome screening markers in pregnancies achieved through assisted reproductive technologies (ART): a FASTER trial study. Prenat Diagn. 2006;26(8):672-8. [pmid: 16764012].
Latin-American Puregon IVF Study Group. A double-blind clinical trial comparing a fixed daily dose of 150 and 250 IU of recombinant follicle-stimulating hormone in women undergoing in vitro fertilization. Fertil Steril. 2001;76(5):950-6. [pmid: 11704116].
Laverge H, De Sutter P, Van der Elst J, et al. A prospective, randomized study comparing day 2 and day 3 embryo transfer in human IVF. Hum Reprod. 2001;16(3):476-80. [pmid: 11228214].
Leader A. Monofollicular Ovulation Induction Study Group. Improved monofollicular ovulation in anovulatory or oligo-ovulatory women after a low-dose step-up protocol with weekly increments of 25 international units of follicle-stimulating hormone. Fertil Steril. 2006;85(6):1766-73. [pmid: 16759926].
Lee TH, Wu MY, Chen HF, et al. Ovarian response and follicular development for single-dose and multiple-dose protocols for gonadotropin-releasing hormone antagonist administration. Fertil Steril. 2005;83(6):1700-7. [pmid: 15950639].
Legro RS, Barnhart HX, Schlaff WD, et al. Clomiphene, metformin, or both for infertility in the polycystic ovary syndrome. N Engl J Med. 2007;356(6):551-66. [pmid: 17287476].
Lenton E, Soltan A, Hewitt J, et al. Induction of ovulation in women undergoing assisted reproductive techniques: recombinant human FSH (follitropin alpha) versus highly purified urinary FSH (urofollitropin HP). Hum Reprod. 2000;15(5):1021-7. [pmid: 10783345].
Lerner-Geva L, Geva E, Lessing JB, et al. The possible association between in vitro fertilization treatments and cancer development. Int J Gynecol Cancer. 2003;13(1):23-7. [pmid: 12631215].
Lerner-Geva L, Keinan-Boker L, Blumstein T, et al. Infertility, ovulation induction treatments and the incidence of breast cancer—a historical prospective cohort of Israeli women. Breast Cancer Research & Treatment. 2006;100(2):201-12. [pmid: 16685587].
Levi-Setti PE, Cavagna M, Bulletti C. Recombinant gonadotrophins associated with GnRH antagonist (cetrorelix) in ovarian stimulation for ICSI: comparison of r-FSH alone and in combination with r-LH. Eur J Obstet Gynecol Reprod Biol. 2006;126(2):212-6. [pmid: 16377062].
Levitas E, Lunenfeld E, Har-Vardi I, et al. Blastocyst-stage embryo transfer in patients who failed to conceive in three or more day 2–3 embryo transfer cycles: a prospective, randomized study. Fertil Steril. 2004;81(3):567-71. [pmid: 15037404].
Lewis V, Queenan J Jr, Hoeger K, et al. Clomiphene citrate monitoring for intrauterine insemination timing: a randomized trial. Fertil Steril. 2006;85(2):401-6. [pmid: 16595218].
Li R, Lu L, Hao G, et al. Abdominal ultrasound-guided embryo transfer improves clinical pregnancy rates after in vitro fertilization: experiences from 330 clinical investigations. J Assist Reprod Genet. 2005;22(1):3-8. [pmid: 15807215].
Lidegaard O, Pinborg A, Andersen AN. Imprinting diseases and IVF: Danish National IVF cohort study. Hum Reprod. 2005;20(4):950-4. [pmid: 15665017].
Lok IH, Chan MT, Chan DL, et al. A prospective randomized trial comparing patient-controlled sedation using propofol and alfentanil and physician-administered sedation using diazepam and pethidine during transvaginal ultrasound-guided oocyte retrieval. Hum Reprod. 2002;17(8):2101-6. [pmid: 12151444].
Loutradis D, Stefanidis K, Drakakis P, et al. A modified gonadotropin-releasing hormone (GnRH) antagonist protocol failed to increase clinical pregnancy rates in comparison with the long GnRH protocol. Fertil Steril. 2004;82(5):1446-8. [pmid: 15533377].
Ludwig M, Felberbaum RE, Devroey P, et al. Significant reduction of the incidence of ovarian hyperstimulation syndrome (OHSS) by using the LHRH antagonist Cetrorelix (Cetrotide) in controlled ovarian stimulation for assisted reproduction. Arch Gynecol Obstet. 2000;264(1):29-32. [pmid: 10985616].
Ludwig M, Finas A, Katalinic A, et al. Prospective, randomized study to evaluate the success rates using hCG, vaginal progesterone or a combination of both for luteal phase support. Acta Obstet Gynecol Scand. 2001;80(6):574-82. [pmid: 11380297].
Ludwig M, Katalinic A. Malformation rate in fetuses and children conceived after ICSI: results of a prospective cohort study. Reproductive Biomedicine Online. 2002;5(2):171-8. [pmid: 12419043].
Ludwig M, Schwartz P, Babahan B, et al. Luteal phase support using either Crinone 8% or Utrogest: results of a prospective, randomized study. Eur J Obstet Gynecol Reprod Biol. 2002;103(1):48-52. [pmid: 12039463].
Lukassen HG, Braat DD, Wetzels AM, et al. Two cycles with single embryo transfer versus one cycle with double embryo transfer: a randomized controlled trial. Hum Reprod. 2005;20(3):702-8. [pmid: 15618254].
Lukaszuk K, Liss J, Lukaszuk M, et al. Optimization of estradiol supplementation during the luteal phase improves the pregnancy rate in women undergoing in vitro fertilization-embryo transfer cycles. Fertil Steril. 2005;83(5):1372-6. [pmid: 15866571].
Luke B, Brown MB, Nugent C, et al. Risk factors for adverse outcomes in spontaneous versus assisted conception twin pregnancies. Fertil Steril. 2004;81(2):315-9. [pmid: 14967366].
Lynch A, McDuffie R, Stephens J, et al. The contribution of assisted conception, chorionicity and other risk factors to very low birthweight in a twin cohort. BJOG. 2003;110(4):405-10. [pmid: 12699803].
Lynch A, McDuffie R Jr, Murphy J, et al. Preeclampsia in multiple gestation: the role of assisted reproductive technologies. Obstet Gynecol. 2002;99(3):445-51. [pmid: 11864672].
Ma S, Rowe T, Yuen BH. Impact of assisted hatching on the outcome of intracytoplasmic sperm injection: a prospective, randomized clinical trial and pregnancy follow-up. Fertil Steril. 2006;85(4):895-900. [pmid: 16580371].
Mahani IM, Davar R. Hyaluronic acid versus albumin in human embryo transfer medium. Eastern Mediterranean Health Journal. 2007;13(4):876-80. [pmid: 17955771].
Maimburg RD, Vaeth M. Do children born after assisted conception have less risk of developing infantile autism?. Hum Reprod. 2007;22(7):1841-3. [pmid: 17456530].
Makrakis E, Angeli I, Agapitou K, et al. Laser versus mechanical assisted hatching: a prospective study of clinical outcomes. Fertil Steril. 2006;86(6):1596-600. [pmid: 17055494].
Malkawi HY, Qublan HS. The effect of metformin plus clomiphene citrate on ovulation and pregnancy rates in clomiphene-resistant women with polycystic ovary syndrome. Saudi Medical Journal. 2002;23(6):663-6. [pmid: 12070543].
Malmusi S, La Marca A, Giulini S, et al. Comparison of a gonadotropin-releasing hormone (GnRH) antagonist and GnRH agonist flare-up regimen in poor responders undergoing ovarian stimulation. Fertil Steril. 2005;84(2):402-6. [pmid: 16084881].
Mamas L. Comparison of fallopian tube sperm perfusion and intrauterine tuboperitoneal insemination: a prospective randomized study. Fertil Steril. 2006;85(3):735-40. [pmid: 16500346].
Manau D, Fabregues F, Arroyo V, et al. Hemodynamic changes induced by urinary human chorionic gonadotropin and recombinant luteinizing hormone used for inducing final follicular maturation and luteinization. Fertil Steril. 2002;78(6):1261-7. [pmid: 12477522].
Manoura A, Korakaki E, Hatzidaki E, et al. Perinatal outcome of twin pregnancies after in vitro fertilization. Acta Obstet Gynecol Scand. 2004;83(11):1079-84. [pmid: 15488126].
Marci R, Caserta D, Dolo V, et al. GnRH antagonist in IVF poor-responder patients: results of a randomized trial. Reproductive Biomedicine Online. 2005;11(2):189-93. [pmid: 16168215].
Marrs R, Meldrum D, Muasher S, et al. Randomized trial to compare the effect of recombinant human FSH (follitropin alfa) with or without recombinant human LH in women undergoing assisted reproduction treatment. Reproductive Biomedicine Online. 2004;8(2):175-82. [pmid: 14989794].
Martinez F, Coroleu B, Parera N, et al. Human chorionic gonadotropin and intravaginal natural progesterone are equally effective for luteal phase support in IVF. Gynecol Endocrinol. 2000;14(5):316-20. [pmid: 11109970].
Martinez F, Coroleu B, Parriego M, et al. Ultrasound-guided embryo transfer: immediate withdrawal of the catheter versus a 30 second wait. Hum Reprod. 2001;16(5):871-4. [pmid: 11331631].
Mastenbroek S, Twisk M, van Echten-Arends J, et al. In vitro fertilization with preimplantation genetic screening. N Engl J Med. 2007;357(1):9-17. [pmid: 17611204].
Matias A, Oliveira C, da Silva JT, et al. The effect of ICSI, maternal age, and embryonic stage on early clinical loss rate of twin versus singleton pregnancies. Eur J Obstet Gynecol Reprod Biol. 2007;130(2):212-5. [pmid: 16806650].
Matorras R, Recio V, Corcostegui B, et al. Recombinant human FSH versus highly purified urinary FSH: a randomized study in intrauterine insemination with husbands' spermatozoa. Hum Reprod. 2000;15(6):1231-4. [pmid: 10831546].
Matorras R, Urquijo E, Mendoza R, et al. Ultrasound-guided embryo transfer improves pregnancy rates and increases the frequency of easy transfers. Hum Reprod. 2002;17(7):1762-6. [pmid: 12093836].
Maymon R, Jauniaux E, Holmes A, et al. Nuchal translucency measurement and pregnancy outcome after assisted conception versus spontaneously conceived twins. Hum Reprod. 2001;16(9):1999-2004. [pmid: 11527912].
Maymon R, Shulman A. Integrated first- and second-trimester Down syndrome screening test among unaffected IVF pregnancies. Prenat Diagn. 2004;24(2):125-9. [pmid: 14974121].
Maymon R, Shulman A. Serial first- and second-trimester Down's syndrome screening tests among IVF-versus naturally-conceived singletons. Hum Reprod. 2002;17(4):1081-5. [pmid: 11925409].
McIlveen M, Lok FD, Pritchard J, et al. Modern embryo transfer catheters and pregnancy outcome: a prospective randomized trial. Fertil Steril. 2005;84(4):996-1000. [pmid: 16213855].
McMahon C, Gibson F. A special path to parenthood: parent-child relationships in families giving birth to singleton infants through IVF. Reproductive Biomedicine Online. 2002;5(2):179-86. [pmid: 12419044].
Meijer WM, de Jong-Van den Berg LT, van den Berg MD, et al. Clomiphene and hypospadias on a detailed level: signal or chance?. Birth Defects Research. 2006;76(4):249-52. [pmid: 16586447].
Merlob P, Sapir O, Sulkes J, et al. The prevalence of major congenital malformations during two periods of time, 1986-1994 and 1995-2002 in newborns conceived by assisted reproduction technology. European Journal of Medical Genetics. 2005;48(1):5-11. [pmid: 15953400].
Mikkelsen AL, Smith S, Lindenberg S. Possible factors affecting the development of oocytes in in-vitro maturation. Hum Reprod. 2000;15(Suppl 5):11-7. [pmid: 11263532].
Mochtar MH. Dutch Ganirelix Study Group. The effect of an individualized GnRH antagonist protocol on folliculogenesis in IVF/ICSI. Hum Reprod. 2004;19(8):1713-8. [pmid: 15229205].
Mochtar MH, Van Wely M, Van der Veen F. Timing luteal phase support in GnRH agonist down-regulated IVF/embryo transfer cycles. Hum Reprod. 2006;21(4):905-8. [pmid: 16373409].
Mohamed MA, Sbracia M, Pacchiarotti A, et al. Urinary follicle-stimulating hormone (FSH) is more effective than recombinant FSH in older women in a controlled randomized study. Fertil Steril. 2006;85(5):1398-403. [pmid: 16600226].
Moll E, Bossuyt PM, Korevaar JC, et al. Effect of clomifene citrate plus metformin and clomifene citrate plus placebo on induction of ovulation in women with newly diagnosed polycystic ovary syndrome: randomised double blind clinical trial. BMJ. 2006;332(7556):1485. [pmid: 16769748]. [pmcid: 1482338].
Montag M, van der Ven K, Dorn C, et al. Extended embryo culture reduces the implantation rate on day 4 and day 5 when only a maximum of three embryos are cultured beyond the pronuclear stage. Eur J Obstet Gynecol Reprod Biol. 2006;124(1):65-9. [pmid: 16188376].
Moon HS, Park SH, Lee JO, et al. Treatment with piroxicam before embryo transfer increases the pregnancy rate after in vitro fertilization and embryo transfer. Fertil Steril. 2004;82(4):816-20. [pmid: 15482753].
Moon SY, Choi YS, Ku SY, et al. Comparison of the efficacy and safety of a new recombinant human follicle-stimulating hormone (DA-3801) with follitropin-alpha (Gonal-F) in women undergoing controlled ovarian hyperstimulation for assisted reproductive technology. J Obstet Gynaecol Res. 2007;33(3):305-15. [pmid: 17578360].
Morgia F, Sbracia M, Schimberni M, et al. A controlled trial of natural cycle versus microdose gonadotropin-releasing hormone analog flare cycles in poor responders undergoing in vitro fertilization. Fertil Steril. 2004;81(6):1542-7. [pmid: 15193474].
Morgia F, Torti M, Montigiani M, et al. Use of a medium buffered with N-hydroxyethylpiperazine-N-ethanesulfonate (HEPES) in intracytoplasmic sperm injection procedures is detrimental to the outcome of in vitro fertilization. Fertil Steril. 2006;85(5):1415-9. [pmid: 16600227].
Muller F, Dreux S, Lemeur A, et al. Medically assisted reproduction and second-trimester maternal serum marker screening for Down syndrome. Prenat Diagn. 2003;23(13):1073-6. [pmid: 14691995].
Murphy MF, Neale RE, Hey K, et al. Pregnancy outcome among twins conceived after subfertility treatment compared with natural twins: A population-based study. Twin Research & Human Genetics: the Official Journal of the International Society for Twin Studies. 2006;9(2):279-84. [pmid: 16611499].
Nadir Ciray H, Bener F, Karagenc L, et al. Impact of assisted hatching on ART outcome in women with endometriosis. Hum Reprod. 2005;20(9):2546-9. [pmid: 15905297].
Nagy ZP, Taylor T, Elliott T, et al. Removal of lysed blastomeres from frozen-thawed embryos improves implantation and pregnancy rates in frozen embryo transfer cycles. Fertil Steril. 2005;84(6):1606-12. [pmid: 16359953].
Nassar AH, Usta IM, Rechdan JB, et al. Pregnancy outcome in spontaneous twins versus twins who were conceived through in vitro fertilization. Am J Obstet Gynecol. 2003;189(2):513-8. [pmid: 14520227].
Ng EH, Chui DK, Tang OS, et al. Paracervical block with and without conscious sedation: a comparison of the pain levels during egg collection and the postoperative side effects. Fertil Steril. 2001;75(4):711-7. [pmid: 11287024].
Ng EH, Lau EY, Yeung WS, et al. HMG is as good as recombinant human FSH in terms of oocyte and embryo quality: a prospective randomized trial. Hum Reprod. 2001;16(2):319-25. [pmid: 11157827].
Ng EH, Makkar G, Yeung WS, et al. A randomized comparison of three insemination methods in an artificial insemination program using husbands' semen. J Reprod Med. 2003;48(7):542-6. [pmid: 12953328].
Ng EH, Miao B, Cheung W, et al. A randomised comparison of side effects and patient inconvenience of two vaginal progesterone formulations used for luteal support in in vitro fertilisation cycles. Eur J Obstet Gynecol Reprod Biol. 2003;111(1):50-4. [pmid: 14557011].
Ng EH, Naveed F, Lau EY, et al. A randomized double-blind controlled study of the efficacy of laser-assisted hatching on implantation and pregnancy rates of frozen-thawed embryo transfer at the cleavage stage. Hum Reprod. 2005;20(4):979-85. [pmid: 15665025].
Ng EH, Wat NM, Ho PC. Effects of metformin on ovulation rate, hormonal and metabolic profiles in women with clomiphene-resistant polycystic ovaries: a randomized, double-blinded placebo-controlled trial. Hum Reprod. 2001;16(8):1625-31. [pmid: 11473953].
Ng EY, Yeung WS, Ho PC. Comparison of two dosages of recombinant human follicle-stimulating hormone in Chinese women undergoing controlled ovarian stimulation: prospective randomised double-blind study. Hong Kong Medical Journal. 2000;6(4):368-74. [pmid: 11177158].
Nyboe Andersen A, Popovic-Todorovic B, Schmidt KT, et al. Progesterone supplementation during early gestations after IVF or ICSI has no effect on the delivery rates: a randomized controlled trial. Hum Reprod. 2002;17(2):357-61. [pmid: 11821278].
Ochsenkuhn R, Strowitzki T, Gurtner M, et al. Pregnancy complications, obstetric risks, and neonatal outcome in singleton and twin pregnancies after GIFT and IVF. Arch Gynecol Obstet. 2003;268(4):256-61. [pmid: 12904987].
Ohl J, Lefebvre-Maunoury C, Wittemer C, et al. Nitric oxide donors for patients undergoing IVF. A prospective, double-blind, randomized, placebo-controlled trial. Hum Reprod. 2002;17(10):2615-20. [pmid: 12351537].
Olivennes F, Belaisch-Allart J, Emperaire JC, et al. Prospective, randomized, controlled study of in vitro fertilization-embryo transfer with a single dose of a luteinizing hormone-releasing hormone (LH-RH) antagonist (cetrorelix) or a depot formula of an LH-RH agonist (triptorelin). Fertil Steril. 2000;73(2):314-20. [pmid: 10685535].
Olson CK, Keppler-Noreuil KM, Romitti PA, et al. In vitro fertilization is associated with an increase in major birth defects. Fertil Steril. 2005;84(5):1308-15. [pmid: 16275219].
Ombelet W, Martens G, De Sutter P, et al. Perinatal outcome of 12,021 singleton and 3108 twin births after non-IVF-assisted reproduction: a cohort study. Hum Reprod. 2006;21(4):1025-32. [pmid: 16339165].
Orlandi F, Rossi C, Allegra A, et al. First trimester screening with free beta-hCG, PAPP-A and nuchal translucency in pregnancies conceived with assisted reproduction. Prenat Diagn. 2002;22(8):718-21. [pmid: 12210583].
Ortega-Gonzalez C, Luna S, Hernandez L, et al. Responses of serum androgen and insulin resistance to metformin and pioglitazone in obese, insulin-resistant women with polycystic ovary syndrome. J Clin Endocrinol Metab. 2005;90(3):1360-5. [pmid: 15598674].
Orvieto R, Kerner R, Krissi H, et al. Comparison of leuprolide acetate and triptorelin in assisted reproductive technology cycles: a prospective, randomized study. Fertil Steril. 2002;78(6):1268-71. [pmid: 12477523].
Out HJ, David I, Ron-El R, et al. A randomized, double-blind clinical trial using fixed daily doses of 100 or 200 IU of recombinant FSH in ICSI cycles. Hum Reprod. 2001;16(6):1104-9. [pmid: 11387277].
Out HJ, Rutherford A, Fleming R, et al. A randomized, double-blind, multicentre clinical trial comparing starting doses of 150 and 200 IU of recombinant FSH in women treated with the GnRH antagonist ganirelix for assisted reproduction. Hum Reprod. 2004;19(1):90-5. [pmid: 14688163].
Pabuccu R, Onalan G, Kaya C. GnRH agonist and antagonist protocols for stage I–II endometriosis and endometrioma in in vitro fertilization/intracytoplasmic sperm injection cycles. Fertil Steril. 2007;88(4):832-9. [pmid: 17428479].
Pacchiarotti A, Aragona C, Gaglione R, et al. Efficacy of a combined protocol of urinary and recombinant follicle-stimulating hormone used for ovarian stimulation of patients undergoing ICSI cycle. J Assist Reprod Genet. 2007;24(9):400-5. [pmid: 17653846].
Pakkila M, Rasanen J, Heinonen S, et al. Low-dose aspirin does not improve ovarian responsiveness or pregnancy rate in IVF and ICSI patients: a randomized, placebo-controlled double-blind study. Hum Reprod. 2005;20(8):2211-4. [pmid: 15817582].
Palomba S, Falbo A, Orio F Jr, et al. A randomized controlled trial evaluating metformin pre-treatment and co-administration in non-obese insulin-resistant women with polycystic ovary syndrome treated with controlled ovarian stimulation plus timed intercourse or intrauterine insemination. Hum Reprod. 2005;20(10):2879-86. [pmid: 15958399].
Palomba S, Orio F Jr, Falbo A, et al. Prospective parallel randomized, double-blind, double-dummy controlled clinical trial comparing clomiphene citrate and metformin as the first-line treatment for ovulation induction in nonobese anovulatory women with polycystic ovary syndrome. J Clin Endocrinol Metab. 2005;90(7):4068-74. [pmid: 15840746].
Palomba S, Orio F Jr, Falbo A, et al. Metformin administration and laparoscopic ovarian drilling improve ovarian response to clomiphene citrate (CC) in oligo-anovulatory CC-resistant women with polycystic ovary syndrome. Clin Endocrinol (Oxf). 2005;63(6):631-5. [pmid: 16343096].
Palomba S, Orio F Jr, Nardo LG, et al. Metformin administration versus laparoscopic ovarian diathermy in clomiphene citrate-resistant women with polycystic ovary syndrome: a prospective parallel randomized double-blind placebo-controlled trial. J Clin Endocrinol Metab. 2004;89(10):4801-9. [pmid: 15472166].
Pantos K, Makrakis E, Stavrou D, et al. Comparison of embryo transfer on day 2, day 3, and day 6: a prospective randomized study. Fertil Steril. 2004;81(2):454-5. [pmid: 14967390].
Papanikolaou EG, Camus M, Kolibianakis EM, et al. In vitro fertilization with single blastocyst-stage versus single cleavage-stage embryos. N Engl J Med. 2006;354(11):1139-46. [pmid: 16540614].
Papanikolaou EG, D'haeseleer E, Verheyen G, et al. Live birth rate is significantly higher after blastocyst transfer than after cleavage-stage embryo transfer when at least four embryos are available on day 3 of embryo culture. A randomized prospective study. Hum Reprod. 2005;20(11):3198-203. [pmid: 16055454].
Parazzini F, Pelucchi C, Negri E, et al. Use of fertility drugs and risk of ovarian cancer. Hum Reprod. 2001;16(7):1372-5. [pmid: 11425815].
Pellicano M, Zullo F, Fiorentino A, et al. Conscious sedation versus general anaesthesia for minilaparoscopic gamete intra-Fallopian transfer: a prospective randomized study. Hum Reprod. 2001;16(11):2295-7. [pmid: 11679507].
Perez-Medina T, Bajo-Arenas J, Salazar F, et al. Endometrial polyps and their implication in the pregnancy rates of patients undergoing intrauterine insemination: a prospective, randomized study. Hum Reprod. 2005;20(6):1632-5. [pmid: 15760959].
Perri T, Chen R, Yoeli R, et al. Are singleton assisted reproductive technology pregnancies at risk of prematurity?. J Assist Reprod Genet. 2001;18(5):245-9. [pmid: 11464574].
Petersen CG, Mauri AL, Baruffi RL, et al. Implantation failures: success of assisted hatching with quarter-laser zona thinning. Reproductive Biomedicine Online. 2005;10(2):224-9. [pmid: 15823228].
Petersen CG, Mauri AL, Baruffi RL, et al. Zona thinning with a noncontact diode laser in ICSI embryos from women of advanced age. J Assist Reprod Genet. 2002;19(11):512-6. [pmid: 12484493].
Pinborg A, Lidegaard O, Freiesleben NC, et al. Vanishing twins: a predictor of small-for-gestational age in IVF singletons. Hum Reprod. 2007;22(10):2707-14. [pmid: 17728356].
Pinborg A, Lidegaard O, la Cour Freiesleben N, et al. Consequences of vanishing twins in IVF/ICSI pregnancies. Hum Reprod. 2005;20(10):2821-9. [pmid: 15979998].
Pinborg A, Loft A, Rasmussen S, et al. Hospital care utilization of IVF/ICSI twins followed until 2–7 years of age: a controlled Danish national cohort study. Hum Reprod. 2004;19(11):2529-36. [pmid: 15319391].
Pinborg A, Loft A, Rasmussen S, et al. Neonatal outcome in a Danish national cohort of 3438 IVF/ICSI and 10,362 non-IVF/ICSI twins born between 1995 and 2000. Hum Reprod. 2004;19(2):435-41. [pmid: 14747193].
Pinborg A, Loft A, Schmidt L, et al. Attitudes of IVF/ICSI-twin mothers towards twins and single embryo transfer. Hum Reprod. 2003;18(3):621-7. [pmid: 12615836].
Pinborg A, Loft A, Schmidt L, et al. Morbidity in a Danish national cohort of 472 IVF/ICSI twins, 1132 non-IVF/ICSI twins and 634 IVF/ICSI singletons: health-related and social implications for the children and their families. Hum Reprod. 2003;18(6):1234-43. [pmid: 12773452].
Pinborg A, Loft A, Schmidt L, et al. Neurological sequelae in twins born after assisted conception: controlled national cohort study. BMJ. 2004;329(7461):311. [pmid: 15256418]. [pmcid: 506847].
Pinborg A, Loft A, Schmidt L, et al. Maternal risks and perinatal outcome in a Danish national cohort of 1005 twin pregnancies: the role of in vitro fertilization. Acta Obstet Gynecol Scand. 2004;83(1):75-84. [pmid: 14678089].
Pinheiro OL, Cavagna M, Baruffi RL, et al. Administration of beta-2 adrenergic agonists during the peri-implantation period does not improve implantation or pregnancy rates in intracytoplasmic sperm injection (ICSI) cycles. J Assist Reprod Genet. 2003;20(12):513-6. [pmid: 15035551].
Place I, Englert Y. A prospective longitudinal study of the physical, psychomotor, and intellectual development of singleton children up to 5 years who were conceived by intracytoplasmic sperm injection compared with children conceived spontaneously and by in vitro fertilization. Fertil Steril. 2003;80(6):1388-97. [pmid: 14667874].
Platteau P, Laurent E, Albano C, et al. An open, randomized single-centre study to compare the efficacy and convenience of follitropin beta administered by a pen device with follitropin alpha administered by a conventional syringe in women undergoing ovarian stimulation for IVF/ICSI. Hum Reprod. 2003;18(6):1200-4. [pmid: 12773446].
Poehl M, Holagschwandtner M, Bichler K, et al. IVF-patients with nonmale factor “to ICSI” or “not to ICSI” that is the question?. J Assist Reprod Genet. 2001;18(4):205-8. [pmid: 11432111].
Poikkeus P, Gissler M, Unkila-Kallio L, et al. Obstetric and neonatal outcome after single embryo transfer. Hum Reprod. 2007;22(4):1073-9. [pmid: 17251357].
Poikkeus P, Saisto T, Unkila-Kallio L, et al. Fear of childbirth and pregnancy-related anxiety in women conceiving with assisted reproduction. Obstet Gynecol. 2006;108(1):70-6. [pmid: 16816058].
Poikkeus P, Unkila-Kallio L, Vilska S, et al. Impact of infertility characteristics and treatment modalities on singleton pregnancies after assisted reproduction. Reproductive Biomedicine Online. 2006;13(1):135-44. [pmid: 16820125].
Popovic-Todorovic B, Loft A, Bredkjaeer HE, et al. A prospective randomized clinical trial comparing an individual dose of recombinant FSH based on predictive factors versus a ‘standard’ dose of 150 IU/day in ‘standard’ patients undergoing IVF/ICSI treatment. Hum Reprod. 2003;18(11):2275-82. [pmid: 14585873].
Primi MP, Senn A, Montag M, et al. A European multicentre prospective randomized study to assess the use of assisted hatching with a diode laser and the benefit of an immunosuppressive/antibiotic treatment in different patient populations. Hum Reprod. 2004;19(10):2325-33. [pmid: 15284215].
Propst AM, Bates GW, Robinson RD, et al. A randomized controlled trial of increasing recombinant follicle-stimulating hormone after initiating a gonadotropin-releasing hormone antagonist for in vitro fertilization-embryo transfer. Fertil Steril. 2006;86(1):58-63. [pmid: 16753156].
Propst AM, Hill JA, Ginsburg ES, et al. A randomized study comparing Crinone 8% and intramuscular progesterone supplementation in in vitro fertilization-embryo transfer cycles. Fertil Steril. 2001;76(6):1144-9. [pmid: 11730742].
Putterman S, Figueroa R, Garry D, et al. Comparison of obstetric outcomes in twin pregnancies after in vitro fertilization, ovarian stimulation and spontaneous conception. Journal of Maternal-Fetal & Neonatal Medicine. 2003;14(4):237-40. [pmid: 14738169].
Puumala SE, Ross JA, Olshan AF, et al. Reproductive history, infertility treatment, and the risk of acute leukemia in children with down syndrome: a report from the Children's Oncology Group. Cancer. 2007;110(9):2067-74. [pmid: 17849462].
Qublan HS, Amarin Z, Tahat YA, et al. Ovarian cyst formation following GnRH agonist administration in IVF cycles: incidence and impact. Hum Reprod. 2006;21(3):640-4. [pmid: 16253965].
Quinn P, Cooke S. Equivalency of culture media for human in vitro fertilization formulated to have the same pH under an atmosphere containing 5% or 6% carbon dioxide. Fertil Steril. 2004;81(6):1502-6. [pmid: 15193468].
Ragni G, Alagna F, Brigante C, et al. GnRH antagonists and mild ovarian stimulation for intrauterine insemination: a randomized study comparing different gonadotrophin dosages. Hum Reprod. 2004;19(1):54-8. [pmid: 14688156].
Rajesh H, Yap HA, Wu YJ. Pregnancy outcomes from in-vitro fertilisation and intracytoplasmic sperm injection: a comparison. Singapore Med J. 2006;47(4):309-14. [pmid: 16572243].
Rama Raju GA, Shashi Kumari G, Krishna KM, et al. Assessment of uterine cavity by hysteroscopy in assisted reproduction programme and its influence on pregnancy outcome. Arch Gynecol Obstet. 2006;274(3):160-4. [pmid: 16715289].
Raty R, Virtanen A, Koskinen P, et al. Maternal midtrimester serum AFP and free beta-hCG levels in in vitro fertilization twin pregnancies. Prenat Diagn. 2000;20(3):221-3. [pmid: 10719325].
Raziel A, Friedler S, Schachter M, et al. Increased early pregnancy loss in IVF patients with severe ovarian hyperstimulation syndrome. Hum Reprod. 2002;17(1):107-10. [pmid: 11756371].
Reefhuis J, Honein MA, Shaw GM, et al. Fertility treatments and craniosynostosis: California, Georgia, and Iowa, 1993-1997. Pediatrics. 2003;111(5 Part 2):1163-6. [pmid: 12728131].
Repokari L, Punamaki RL, Poikkeus P, et al. Ante- and perinatal factors and child characteristics predicting parenting experience among formerly infertile couples during the child's first year: a controlled study. Journal of Family Psychology. 2006;20(4):670-9. [pmid: 17176203].
Repokari L, Punamaki RL, Unkila-Kallio L, et al. Infertility treatment and marital relationships: a 1-year prospective study among successfully treated ART couples and their controls. Hum Reprod. 2007;22(5):1481-91. [pmid: 17307807].
Revelli A, Poso F, Gennarelli G, et al. Recombinant versus highly-purified, urinary follicle-stimulating hormone (r-FSH vs. HP-uFSH) in ovulation induction: a prospective, randomized study with cost-minimization analysis. Reproductive Biology & Endocrinology. 2006;4:38. [pmid: 16848893]. [pmcid: 1550405].
Rhodes TL, Higdon HL 3rd, Boone WR. Comparison of pregnancy rates for two embryo-transfer catheters. Fertil Steril. 2007;87(2):411-6. [pmid: 17094973].
Rice JD, McIntosh SF, Halstead AC. Second-trimester maternal serum screening for Down syndrome in in vitro fertilization pregnancies. Prenat Diagn. 2005;25(3):234-8. [pmid: 15791658].
Rickes D, Nickel I, Kropf S, et al. Increased pregnancy rates after ultralong postoperative therapy with gonadotropin-releasing hormone analogs in patients with endometriosis. Fertil Steril. 2002;78(4):757-62. [pmid: 12372452].
Rizk AY, Bedaiwy MA, Al-Inany HG. N-acetyl-cysteine is a novel adjuvant to clomiphene citrate in clomiphene citrate-resistant patients with polycystic ovary syndrome. Fertil Steril. 2005;83(2):367-70. [pmid: 15705376].
Rombauts L, Healy D, Norman RJ, et al. A comparative randomized trial to assess the impact of oral contraceptive pretreatment on follicular growth and hormone profiles in GnRH antagonist-treated patients [erratum appears in Hum Reprod. 2006 Nov;21(11):3032]. Hum Reprod. 2006;21(1):95-103. [pmid: 16253978].
Romundstad LB, Romundstad PR, Sunde A, et al. Increased risk of placenta previa in pregnancies following IVF/ICSI; a comparison of ART and non-ART pregnancies in the same mother. Hum Reprod. 2006;21(9):2353-8. [pmid: 16728419].
Rossing MA, Tang MT, Flagg EW, et al. A case-control study of ovarian cancer in relation to infertility and the use of ovulation-inducing drugs. Am J Epidemiol. 2004;160(11):1070-8. [pmid: 15561986].
Roudebush WE, Toledo AA, Kort HI, et al. Platelet-activating factor significantly enhances intrauterine insemination pregnancy rates in non-male factor infertility.[erratum appears in Fertil Steril. 2004 Sep;82(3):768]. Fertil Steril. 82(1):52-6. [pmid: 15236989].
Rouzi AA, Ardawi MS. A randomized controlled trial of the efficacy of rosiglitazone and clomiphene citrate versus metformin and clomiphene citrate in women with clomiphene citrate-resistant polycystic ovary syndrome. Fertil Steril. 2006;85(2):428-35. [pmid: 16595222].
Rufas-Sapir O, Stein A, Orvieto R, et al. Is assisted hatching beneficial in patients with recurrent implantation failures?. Clin Exp Obstet Gynecol. 2004;31(2):110-2. [pmid: 15266762].
Sagoskin AW, Levy MJ, Tucker MJ, et al. Laser assisted hatching in good prognosis patients undergoing in vitro fertilization-embryo transfer: a randomized controlled trial. Fertil Steril. 2007;87(2):283-7. [pmid: 17094975].
Sakhel K, Khedr M, Schwark S, et al. Comparison of urinary and recombinant human chorionic gonadotropin during ovulation induction in intrauterine insemination cycles: a prospective randomized clinical trial. Fertil Steril. 2007;87(6):1357-62. [pmid: 17433313].
Sauer MV, Thornton MH 2nd, Schoolcraft W, et al. Comparative efficacy and safety of cetrorelix with or without mid-cycle recombinant LH and leuprolide acetate for inhibition of premature LH surges in assisted reproduction. Reproductive Biomedicine Online. 2004;9(5):487-93. [pmid: 15588464].
Saygan-Karamursel B, Tekam O, Aksu T, et al. Perinatal outcomes of spontaneous twins compared with twins conceived through intracytoplasmic sperm injection. J Perinat Med. 2006;34(2):132-8. [pmid: 16519618].
Sbracia M, Farina A, Poverini R, et al. Short versus long gonadotropin-releasing hormone analogue suppression protocols for superovulation in patients > or = 40 years old undergoing intracytoplasmic sperm injection. Fertil Steril. 2005;84(3):644-8. [pmid: 16169397].
Schachter M, Raziel A, Friedler S, et al. Monozygotic twinning after assisted reproductive techniques: a phenomenon independent of micromanipulation. Hum Reprod. 2001;16(6):1264-9. [pmid: 11387303].
Schats R, Sutter PD, Bassil S, et al. Ovarian stimulation during assisted reproduction treatment: a comparison of recombinant and highly purified urinary human FSH. On behalf of The Feronia and Apis study group. Hum Reprod. 2000;15(8):1691-7. [pmid: 10920087].
Schieve LA, Meikle SF, Ferre C, et al. Low and very low birth weight in infants conceived with use of assisted reproductive technology. N Engl J Med. 2002;346(10):731-7. [pmid: 11882728].
Schieve LA, Tatham L, Peterson HB, et al. Spontaneous abortion among pregnancies conceived using assisted reproductive technology in the United States. Obstet Gynecol. 2003;101(5 Pt 1):959-67. [pmid: 12738158].
Schimmel MS, Hammerman C, Lusky A, et al. Very low-birth-weight-infants conceived by in vitro fertilization are not at higher risk for mortality and morbidity: a population-based study. Fertil Steril. 2006;85(4):907-12. [pmid: 16580373].
Scholtes MC, Schnittert B, van Hoogstraten D, et al. A comparison of 3-day and daily follicle-stimulating hormone injections on stimulation days 1–6 in women undergoing controlled ovarian hyperstimulation. Fertil Steril. 2004;81(4):996-1001. [pmid: 15066454].
Selman HA, De Santo M, Sterzik K, et al. Effect of highly purified urinary follicle-stimulating hormone on oocyte and embryo quality. Fertil Steril. 2002;78(5):1061-7. [pmid: 12413994].
Serafini P, Yadid I, Motta EL, et al. Ovarian stimulation with daily late follicular phase administration of low-dose human chorionic gonadotropin for in vitro fertilization: a prospective, randomized trial. Fertil Steril. 2006;86(4):830-8. [pmid: 16963040].
Sharma M, Kriplani A, Agarwal N. Laparoscopic bipolar versus unipolar ovarian drilling in infertile women with resistant polycystic ovarian syndrome: a pilot study. Journal of Gynecologic Surgery. 2006;22:105-11.
Sheard C, Cox S, Oates M, et al. Impact of a multiple, IVF birth on post-partum mental health: a composite analysis. Hum Reprod. 2007;22(7):2058-65. [pmid: 17545565].
Sheiner E, Shoham-Vardi I, Hershkovitz R, et al. Infertility treatment is an independent risk factor for cesarean section among nulliparous women aged 40 and above. Am J Obstet Gynecol. 2001;185(4):888-92. [pmid: 11641672].
Shevell T, Malone FD, Vidaver J, et al. Assisted reproductive technology and pregnancy outcome. Obstet Gynecol. 2005;106(5 Pt 1):1039-45. [pmid: 16260523].
Sifer C, Sellami A, Poncelet C, et al. A prospective randomized study to assess the benefit of partial zona pellucida digestion before frozen-thawed embryo transfers. Hum Reprod. 2006;21(9):2384-9. [pmid: 16772285].
Sills ES, Moomjy M, Zaninovic N, et al. Human zona pellucida micromanipulation and monozygotic twinning frequency after IVF. Hum Reprod. 2000;15(4):890-5. [pmid: 10739838].
Simons AH, Roelofs HJ, Schmoutziguer AP, et al. Early cessation of triptorelin in in vitro fertilization: a double-blind, randomized study. Fertil Steril. 2005;83(4):889-96. [pmid: 15820796].
Smith C, Coyle M, Norman RJ. Influence of acupuncture stimulation on pregnancy rates for women undergoing embryo transfer. Fertil Steril. 2006;85(5):1352-8. [pmid: 16600225].
Soares SR, Troncoso C, Bosch E, et al. Age and uterine receptiveness: predicting the outcome of oocyte donation cycles. J Clin Endocrinol Metab. 2005;90(7):4399-404. [pmid: 15797956].
Spandorfer SD, Davis OK, Barmat LI, et al. Relationship between maternal age and aneuploidy in in vitro fertilization pregnancy loss. Fertil Steril. 2004;81(5):1265-9. [pmid: 15136087].
Staessen C, Platteau P, Van Assche E, et al. Comparison of blastocyst transfer with or without preimplantation genetic diagnosis for aneuploidy screening in couples with advanced maternal age: a prospective randomized controlled trial. Hum Reprod. 2004;19(12):2849-58. [pmid: 15471934].
Stener-Victorin E, Waldenstrom U, Wikland M, et al. Electro-acupuncture as a peroperative analgesic method and its effects on implantation rate and neuropeptide Y concentrations in follicular fluid. Hum Reprod. 2003;18(7):1454-60. [pmid: 12832372].
Stephenson MD, Fluker MR. Treatment of repeated unexplained in vitro fertilization failure with intravenous immunoglobulin: a randomized, placebo-controlled Canadian trial. Fertil Steril. 2000;74(6):1108-13. [pmid: 11119735].
Stern C, Chamley L, Norris H, et al. A randomized, double-blind, placebo-controlled trial of heparin and aspirin for women with in vitro fertilization implantation failure and antiphospholipid or antinuclear antibodies. Fertil Steril. 2003;80(2):376-83. [pmid: 12909502].
Strehler E, Abt M, El-Danasouri I, et al. Impact of recombinant follicle-stimulating hormone and human menopausal gonadotropins on in vitro fertilization outcome. Fertil Steril. 2001;75(2):332-6. [pmid: 11172835].
Stromberg B, Dahlquist G, Ericson A, et al. Neurological sequelae in children born after in-vitro fertilisation: a population-based study. Lancet. 2002;359(9305):461-5. [pmid: 11853790].
Sun Y, Vestergaard M, Christensen J, et al. Epilepsy and febrile seizures in children of treated and untreated subfertile couples. Hum Reprod. 2007;22(1):215-20. [pmid: 16936302].
Surrey ES, Silverberg KM, Surrey MW, et al. Effect of prolonged gonadotropin-releasing hormone agonist therapy on the outcome of in vitro fertilization-embryo transfer in patients with endometriosis. Fertil Steril. 2002;78(4):699-704. [pmid: 12372443].
Sutcliffe AG, Taylor B, Saunders K, et al. Outcome in the second year of life after in-vitro fertilisation by intracytoplasmic sperm injection: a UK case-control study. Lancet. 2001;357(9274):2080-4. [pmid: 11445100].
Sydsjo G, Wadsby M, Kjellberg S, et al. Relationships and parenthood in couples after assisted reproduction and in spontaneous primiparous couples: a prospective long-term follow-up study. Hum Reprod. 2002;17(12):3242-50. [pmid: 12456631].
Tabs D, Vejnovic T, Radunovic N. Preeclampsia and eclampsia in parturients from the in vitro fertilization program. Med Pregl. 2004;57(12):7-12. [pmid: 15327182].
Tang OS, Ng EH, So WW, et al. Ultrasound-guided embryo transfer: a prospective randomized controlled trial. Hum Reprod. 2001;16(11):2310-5. [pmid: 11679510].
Tang T, Glanville J, Orsi N, et al. The use of metformin for women with PCOS undergoing IVF treatment. Hum Reprod. 2006;21(6):1416-25. [pmid: 16501038].
Tarlatzis B, Tavmergen E, Szamatowicz M, et al. The use of recombinant human LH (lutropin alfa) in the late stimulation phase of assisted reproduction cycles: a double-blind, randomized, prospective study. Hum Reprod. 2006;21(1):90-4. [pmid: 16172149].
Tartagni M, Cicinelli E, De Pergola G, et al. Effects of pretreatment with estrogens on ovarian stimulation with gonadotropins in women with premature ovarian failure: a randomized, placebo-controlled trial. Fertil Steril. 2007;87(4):858-61. [pmid: 17261285].
Tay PY, Lenton EA. The impact of luteal supplement on pregnancy outcome following stimulated IVF cycles. Med J Malaysia. 2005;60(2):151-7. [pmid: 16114155].
Tay PY, Lenton EA. Inhibition of progesterone secretion by oestradiol administered in the luteal phase of assisted conception cycles. Med J Malaysia. 2003;58(2):187-95. [pmid: 14569738].
Terry KL, Willett WC, Rich-Edwards JW, et al. A prospective study of infertility due to ovulatory disorders, ovulation induction, and incidence of breast cancer. Arch Intern Med. 2006;166(22):2484-9. [pmid: 17159014].
Tesarik J, Hazout A, Mendoza C. Improvement of delivery and live birth rates after ICSI in women aged >40 years by ovarian co-stimulation with growth hormone. Hum Reprod. 2005;20(9):2536-41. [pmid: 15860489].
Tesarik J, Hazout A, Mendoza-Tesarik R, et al. Beneficial effect of luteal-phase GnRH agonist administration on embryo implantation after ICSI in both GnRH agonist- and antagonist-treated ovarian stimulation cycles. Hum Reprod. 2006;21(10):2572-9. [pmid: 16926261].
Thompson N, Murray S, MacLennan F, et al. A randomised controlled trial of intravenous versus inhalational analgesia during outpatient oocyte recovery. Anaesthesia. 2000;55(8):770-3. [pmid: 10947691].
Thurin A, Hausken J, Hillensjo T, et al. Elective single-embryo transfer versus double-embryo transfer in in vitro fertilization. N Engl J Med. 2004;351(23):2392-402. [pmid: 15575055].
Timmerman-van Kessel EC, Cikot RJ, Dargel-Donkers EJ, et al. A randomized controlled study comparing the endocrine effects of pulsatile intravenous gonadotropin-releasing hormone after gonadotropin-releasing hormone agonist pretreatment versus clomiphene citrate in patients with polycystic ovary syndrome. Fertil Steril. 2000;73(6):1145-8. [pmid: 10856472].
Tremellen KP, Valbuena D, Landeras J, et al. The effect of intercourse on pregnancy rates during assisted human reproduction. Hum Reprod. 2000;15(12):2653-8. [pmid: 11098040].
Tsai YC, Lin MY, Chen SH, et al. Comparing the clinical outcomes of intrauterine insemination by two different density gradient preparation methods. Journal of the Chinese Medical Association: JCMA. 2004;67(4):168-71. [pmid: 15244014].
Tul N, Novak-Antolic Z. Serum PAPP-A levels at 10–14 weeks of gestation are altered in women after assisted conception. Prenat Diagn. 2006;26(13):1206-11. [pmid: 17075793].
Tulandi T, Martin J, Al-Fadhli R, et al. Congenital malformations among 911 newborns conceived after infertility treatment with letrozole or clomiphene citrate. Fertil Steril. 2006;85(6):1761-5. [pmid: 16650422].
Tully LA, Moffitt TB, Caspi A. Maternal adjustment, parenting and child behaviour in families of school-aged twins conceived after IVF and ovulation induction. Journal of Child Psychology & Psychiatry & Allied Disciplines. 2003;44(3):316-25.
Tummers P, De Sutter P, Dhont M. Risk of spontaneous abortion in singleton and twin pregnancies after IVF/ICSI. Hum Reprod. 2003;18(8):1720-3. [pmid: 12871890].
Tworoger SS, Fairfield KM, Colditz GA, et al. Association of oral contraceptive use, other contraceptive methods, and infertility with ovarian cancer risk. Am J Epidemiol. 2007;166(8):894-901. [pmid: 17656616].
Ubaldi F, Rienzi L, Ferrero S, et al. Low dose prednisolone administration in routine ICSI patients does not improve pregnancy and implantation rates. Hum Reprod. 2002;17(6):1544-7. [pmid: 12042275].
Ulug U, Jozwiak EA, Mesut A, et al. Survival rates during the first trimester of multiple gestations achieved by ICSI: a report of 1448 consecutive multiples. Hum Reprod. 2004;19(2):360-4. [pmid: 14747181].
Unfer V, Casini ML, Costabile L, et al. 17 alpha-hydroxyprogesterone caproate versus intravaginal progesterone in IVF-embryo transfer cycles: a prospective randomized study. Reproductive Biomedicine Online. 2004;9(1):17-21. [pmid: 15257811].
Unfer V, Casini ML, Costabile L, et al. High dose of phytoestrogens can reverse the antiestrogenic effects of clomiphene citrate on the endometrium in patients undergoing intrauterine insemination: a randomized trial. J Soc Gynecol Invest. 2004;11(5):323-8.
Unfer V, Casini ML, Gerli S, et al. Phytoestrogens may improve the pregnancy rate in in vitro fertilization-embryo transfer cycles: a prospective, controlled, randomized trial. Fertil Steril. 2004;82(6):1509-13. [pmid: 15589851].
Urman B, Mercan R, Alatas C, et al. Low-dose aspirin does not increase implantation rates in patients undergoing intracytoplasmic sperm injection: a prospective randomized study. J Assist Reprod Genet. 2000;17(10):586-90. [pmid: 11209540].
van Montfoort AP, Fiddelers AA, Janssen JM, et al. In unselected patients, elective single embryo transfer prevents all multiples, but results in significantly lower pregnancy rates compared with double embryo transfer: a randomized controlled trial. Hum Reprod. 2006;21(2):338-43. [pmid: 16253973].
van Weering HG, Schats R, McDonnell J, et al. The impact of the embryo transfer catheter on the pregnancy rate in IVF. Hum Reprod. 2002;17(3):666-70. [pmid: 11870120].
Vandermolen DT, Ratts VS, Evans WS, et al. Metformin increases the ovulatory rate and pregnancy rate from clomiphene citrate in patients with polycystic ovary syndrome who are resistant to clomiphene citrate alone. Fertil Steril. 2001;75(2):310-5. [pmid: 11172832].
Venn A, Hemminki E, Watson L, et al. Mortality in a cohort of IVF patients. Hum Reprod. 2001;16(12):2691-6. [pmid: 11726597].
Vernaeve V, Bonduelle M, Tournaye H, et al. Pregnancy outcome and neonatal data of children born after ICSI using testicular sperm in obstructive and non-obstructive azoospermia. Hum Reprod. 2003;18(10):2093-7. [pmid: 14507827].
Verstraelen H, Goetgeluk S, Derom C, et al. Preterm birth in twins after subfertility treatment: population based cohort study. BMJ. 2005;331(7526):1173. [pmid: 16249191]. [pmcid: 1285094].
Vimpeli T, Tinkanen H, Huhtala H, et al. Salivary and serum progesterone concentrations during two luteal support regimens used in in vitro fertilization treatment. Fertil Steril. 2001;76(4):847-8. [pmid: 11680432].
Vlaisavljevic V, Reljic M, Lovrec VG, et al. Comparable effectiveness using flexible single-dose GnRH antagonist (cetrorelix) and single-dose long GnRH agonist (goserelin) protocol for IVF cycles—a prospective, randomized study. Reproductive Biomedicine Online. 2003;7(3):301-8. [pmid: 14653888].
Vollenhoven B, Clark S, Kovacs G, et al. Prevalence of gestational diabetes mellitus in polycystic ovarian syndrome (PCOS) patients pregnant after ovulation induction with gonadotrophins. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2000;40(1):54-8. [pmid: 10870780].
Vorsselmans A, Platteau P, De Vos A, et al. Comparison of transfers to Fallopian tubes or uterus after ICSI. Reproductive Biomedicine Online. 2003;7(1):82-5. [pmid: 12930581].
Wang JX, Davies MJ, Norman RJ. Polycystic ovarian syndrome and the risk of spontaneous abortion following assisted reproductive technology treatment. Hum Reprod. 2001;16(12):2606-9. [pmid: 11726582].
Wang JX, Norman RJ, Kristiansson P. The effect of various infertility treatments on the risk of preterm birth. Hum Reprod. 2002;17(4):945-9. [pmid: 11925387].
Wang WH, Meng L, Hackett RJ, et al. Rigorous thermal control during intracytoplasmic sperm injection stabilizes the meiotic spindle and improves fertilization and pregnancy rates. Fertil Steril. 2002;77(6):1274-7. [pmid: 12057740].
Weigert M, Krischker U, Pohl M, et al. Comparison of stimulation with clomiphene citrate in combination with recombinant follicle-stimulating hormone and recombinant luteinizing hormone to stimulation with a gonadotropin-releasing hormone agonist protocol: a prospective, randomized study. Fertil Steril. 2002;78(1):34-9. [pmid: 12095487].
Westergaard LG, Erb K, Laursen SB, et al. Human menopausal gonadotropin versus recombinant follicle-stimulating hormone in normogonadotropic women down-regulated with a gonadotropin-releasing hormone agonist who were undergoing in vitro fertilization and intracytoplasmic sperm injection: a prospective randomized study. Fertil Steril. 2001;76(3):543-9. [pmid: 11532479].
Westergaard LG, Mao Q, Krogslund M, et al. Acupuncture on the day of embryo transfer significantly improves the reproductive outcome in infertile women: a prospective, randomized trial. Fertil Steril. 2006;85(5):1341-6. [pmid: 16600232].
Whiteman D, Murphy M, Hey K, et al. Reproductive factors, subfertility, and risk of neural tube defects: a case-control study based on the Oxford Record Linkage Study Register. Am J Epidemiol. 2000;152(9):823-8. [pmid: 11085393].
Wilcox J, Potter D, Moore M, et al. Prospective, randomized trial comparing cetrorelix acetate and ganirelix acetate in a programmed, flexible protocol for premature luteinizing hormone surge prevention in assisted reproductive technologies. Fertil Steril. 2005;84(1):108-17. [pmid: 16009165].
Williams SC, Oehninger S, Gibbons WE, et al. Delaying the initiation of progesterone supplementation results in decreased pregnancy rates after in vitro fertilization: a randomized, prospective study. Fertil Steril. 2001;76(6):1140-3. [pmid: 11730741].
Winter E, Wang J, Davies MJ, et al. Early pregnancy loss following assisted reproductive technology treatment. Hum Reprod. 2002;17(12):3220-3. [pmid: 12456627].
Wojdemann KR, Larsen SO, Shalmi A, et al. First trimester screening for Down syndrome and assisted reproduction: no basis for concern. Prenat Diagn. 2001;21(7):563-5. [pmid: 11494292].
Woldringh GH, Frunt MH, Kremer JA, et al. Decreased ovarian reserve relates to pre-eclampsia in IVF/ICSI pregnancies. Hum Reprod. 2006;21(11):2948-54. [pmid: 16951429].
Wright KP, Guibert J, Weitzen S, et al. Artificial versus stimulated cycles for endometrial preparation prior to frozen-thawed embryo transfer. Reproductive Biomedicine Online. 2006;13(3):321-5. [pmid: 16984757].
Wright V, Schieve LA, Vahratian A, et al. Monozygotic twinning associated with day 5 embryo transfer in pregnancies conceived after IVF. Hum Reprod. 2004;19(8):1831-6. [pmid: 15192064].
Wu HH, Wang NM, Cheng ML, et al. A randomized comparison of ovulation induction and hormone profile between the aromatase inhibitor anastrozole and clomiphene citrate in women with infertility. Gynecol Endocrinol. 2007;23(2):76-81. [pmid: 17454156].
Wu YW, Croen LA, Henning L, et al. Potential association between infertility and spinal neural tube defects in offspring. Birth Defects Research. 2006;76(10):718-22. [pmid: 17022023].
Yarali H, Yildiz BO, Demirol A, et al. Co-administration of metformin during rFSH treatment in patients with clomiphene citrate-resistant polycystic ovarian syndrome: a prospective randomized trial. Hum Reprod. 2002;17(2):289-94. [pmid: 11821265].
Yilmaz B, Kelekci S, Savan K, et al. Addition of human chorionic gonadotropin to clomiphene citrate ovulation induction therapy does not improve pregnancy outcomes and luteal function. Fertil Steril. 2006;85(3):783-6. [pmid: 16500364].
Yim SF, Lok IH, Cheung LP, et al. Dose-finding study for the use of long-acting gonadotrophin-releasing hormone analogues prior to ovarian stimulation for IVF. Hum Reprod. 2001;16(3):492-4. [pmid: 11228217].
Yokoyama Y. Comparison of child-rearing problems between mothers with multiple children who conceived after infertility treatment and mothers with multiple children who conceived spontaneously. Twin Research. 2003;6(2):89-96. [pmid: 12723995].
Yong PY, Brett S, Baird DT, et al. A prospective randomized clinical trial comparing 150 IU and 225 IU of recombinant follicle-stimulating hormone (Gonal-F*) in a fixed-dose regimen for controlled ovarian stimulation in in vitro fertilization treatment. Fertil Steril. 2003;79(2):308-15. [pmid: 12568839].
Zadori J, Kozinszky Z, Orvos H, et al. Birth weight discordance in spontaneous versus induced twins: impact on perinatal outcome. J Assist Reprod Genet. 2004;21(3):85-8. [pmid: 15202736].
Zadori J, Kozinszky Z, Orvos H, et al. The incidence of major birth defects following in vitro fertilization. J Assist Reprod Genet. 2003;20(3):131-2. [pmid: 12735389].
Zadori J, Kozinszky Z, Orvos H, et al. Dilemma of increased obstetric risk in pregnancies following IVF-ET. J Assist Reprod Genet. 2003;20(6):216-21. [pmid: 12877252].
Zaib-un-Nisa S, Ghazal-Aswad S, Badrinath P. Outcome of twin pregnancies after assisted reproductive techniques—a comparative study. Eur J Obstet Gynecol Reprod Biol. 2003;109(1):51-4. [pmid: 12818443].
Zegers-Hochschild F, Balmaceda JP, Fabres C, et al. Prospective randomized trial to evaluate the efficacy of a vaginal ring releasing progesterone for IVF and oocyte donation. Hum Reprod. 2000;15(10):2093-7. [pmid: 11006179].
Zhu JL, Basso O, Obel C, et al. Infertility, infertility treatment, and congenital malformations: Danish national birth cohort. BMJ. 2006;333(7570):679. [pmid: 16893903]. [pmcid: 1584372].
Zhu JL, Obel C, Hammer Bech B, et al. Infertility, infertility treatment, and fetal growth restriction. Obstet Gynecol. 2007;110(6):1326-34. [pmid: 18055728]. [pmcid: 2365892].
Zikopoulos K, Kaponis A, Adonakis G, et al. A prospective randomized study comparing gonadotropin-releasing hormone agonists or gonadotropin-releasing hormone antagonists in couples with unexplained infertility and/or mild oligozoospermia. Fertil Steril. 2005;83(5):1354-62. [pmid: 15866569].
Zuppa AA, Maragliano G, Scapillati ME, et al. Neonatal outcome of spontaneous and assisted twin pregnancies. Eur J Obstet Gynecol Reprod Biol. 2001;95(1):68-72. [pmid: 11267723].