# References Cited in the Evidence Report

1 Speroff L, Fritz MA. Clinical reproductive endocrinology and infertility. 7th ed. Philadelphia: Lippincott Williams & Wilkins; 2004.
2 Chandra A, Martinez GM, Mosher WD, et al. Fertility, family planning, and reproductive health of U.S. women: data from the 2002 National Survey of Family Growth. Vital & Health Statistics - Series 23, Data From the National Survey of Family Growth 2005;(25):1–160.
3 American College of Obstetricians and Gynecologists. Guidelines for women's health care: a resource manual. 3rd edition. Washington, DC: American College of Obstetricians and Gynecologists; 2007.
4 Gnoth C, Godehardt D, Godehardt E, et al. Time to pregnancy: results of the German prospective study and impact on the management of infertility. Hum Reprod. 2003;18(9):1959-66. [pmid: 12923157].
5 Gnoth C, Godehardt E, Frank-Herrmann P, et al. Definition and prevalence of subfertility and infertility. Hum Reprod. 2005;20(5):1144-7. [pmid: 15802321].
6 Legro RS, Barnhart HX, Schlaff WD, et al. Clomiphene, metformin, or both for infertility in the polycystic ovary syndrome. N Engl J Med. 2007;356(6):551-66. [pmid: 17287476].
7 Hughes EG, Beecroft ML, Wilkie V, et al. A multicentre randomized controlled trial of expectant management versus IVF in women with Fallopian tube patency. Hum Reprod. 2004;19(5):1105-9. [pmid: 15044399].
8 Habbema JD, Collins J, Leridon H, et al. Towards less confusing terminology in reproductive medicine: a proposal. Hum Reprod. 2004;19(7):1497-501. [pmid: 15220305].
9 Anonymous. Implementation of the Fertility Clinic Success Rate and Certification Act of 1992: a model program for the certification of embryo laboratories. Federal Register Notice July 21, 1999. Volume 64, Number 139.
10 Wright VC, Chang J, Jeng G, et al. Assisted reproductive technology surveillance - United States, 2004. Morbidity & Mortality Weekly Report. Surveillance Summaries. 2007;56(6):1-22. [pmid: 17557073].
11 Van Voorhis BJ. Clinical practice. In vitro fertilization. N Engl J Med. 2007;356(4):379-86. [pmid: 17251534].
12 Boivin J, Bunting L, Collins JA, et al. International estimates of infertility prevalence and treatment-seeking: potential need and demand for infertility medical care [erratum appears in Hum Reprod. 2007 Oct;22(10):2800]. Hum Reprod. 2007;22(6):1506-12. [pmid: 17376819].
13 Stephen EH, Chandra A. Declining estimates of infertility in the United States: 1982-2002. Fertil Steril. 2006;86(3):516-23. [pmid: 16952500].
14 Centers for Disease Control and Prevention, American Society for Reproductive Medicine, Society for Assisted Reproductive Technology. 2005 Assisted Reproductive Technology Success Rates: National Summary and Fertility Clinic Reports. Atlanta: Centers for Disease Control and Prevention; 2007. Available at: www.cdc.gov/ART/ART2005/index.htm. Accessed 10 January 2008.
15 Barnard L, Ferriday D, Guenther N, et al. Quality of life and psychological well being in polycystic ovary syndrome. Hum Reprod. 2007;22(8):2279-86. [pmid: 17537782].
16 Gao X, Yeh YC, Outley J, et al. Health-related quality of life burden of women with endometriosis: a literature review. Curr Med Res Opin. 2006;22(9):1787-97. [pmid: 16968582].
17 Martinez GM, Chandra A, Abma JC, et al. Fertility, contraception, and fatherhood: data on men and women from cycle 6 (2002) of the 2002 National Survey of Family Growth. Vital & Health Statistics - Series 23, Data From the National Survey of Family Growth 2006;(26):1–142.
18 Cousineau TM, Domar AD. Psychological impact of infertility. Best Pract Res Clin Obstet Gynaecol. 2007;21(2):293-308. [pmid: 17241818].
19 Monga M, Alexandrescu B, Katz SE, et al. Impact of infertility on quality of life, marital adjustment, and sexual function. Urology. 2004;63(1):126-30. [pmid: 14751363].
20 Ragni G, Mosconi P, Baldini MP, et al. Health-related quality of life and need for IVF in 1000 Italian infertile couples. Hum Reprod. 2005;20(5):1286-91. [pmid: 15695309].
21 Fekkes M, Buitendijk SE, Verrips GH, et al. Health-related quality of life in relation to gender and age in couples planning IVF treatment. Hum Reprod. 2003;18(7):1536-43. [pmid: 12832385].
22 Spar DL. The baby business. Boston, MA: Harvard Business School Press, 2006. p. 3.
23 Little SE, Ratcliffe J, Caughey AB. Cost of transferring one through five embryos per in vitro fertilization cycle from various payor perspectives. Obstet Gynecol. 2006;108(3 Pt 1):593-601. [pmid: 16946220].
24 Wolner-Hanssen P, Rydhstroem H. Cost-effectiveness analysis of in-vitro fertilization: estimated costs per successful pregnancy after transfer of one or two embryos. Hum Reprod. 1998;13(1):88-94. [pmid: 9512235].
25 Callahan TL, Hall JE, Ettner SL, et al. The economic impact of multiple-gestation pregnancies and the contribution of assisted-reproduction techniques to their incidence. N Engl J Med. 1994;331(4):244-9. [pmid: 8015572].
26 Jain T, Missmer SA, Hornstein MD. Trends in embryo-transfer practice and in outcomes of the use of assisted reproductive technology in the United States. N Engl J Med. 2004;350(16):1639-45. [pmid: 15084696].
27 Wilson CB. Adoption of new surgical technology. BMJ. 2006;332(7533):112-4. [pmid: 16410591]. [pmcid: 1326944].
28 Strasberg SM, Ludbrook PA. Who oversees innovative practice? Is there a structure that meets the monitoring needs of new techniques?. Journal of the American College of Surgeons. 2003;196(6):938-48. [pmid: 12788432].
29 Nygaard I. What does “FDA Approved” mean for medical devices?. Obstet Gynecol. 2008;111(1):4-6. [pmid: 18165386].
30 Jain T, Harlow BL, Hornstein MD. Insurance coverage and outcomes of in vitro fertilization. N Engl J Med. 2002;347(9):661-6. [pmid: 12200554].
31 Reynolds MA, Schieve LA, Jeng G, et al. Does insurance coverage decrease the risk for multiple births associated with assisted reproductive technology?. Fertil Steril. 2003;80(1):16-23. [pmid: 12849794].
32 Green JA, Robins JC, Scheiber M, et al. Racial and economic demographics of couples seeking infertility treatment. Am J Obstet Gynecol. 2001;184(6):1080-2. [pmid: 11349163].
33 Spar DL. The baby business. Boston, MA: Harvard Business School Press, 2006. pp. 31–68.
34 Jain T, Gupta RS. Trends in the use of intracytoplasmic sperm injection in the United States. N Engl J Med. 2007;357(3):251-7. [pmid: 17634460].
35 Gleicher N, Weghofer A, Barad D. A formal comparison of the practice of assisted reproductive technologies between Europe and the USA. Hum Reprod. 2006;21(8):1945-50. [pmid: 16690628].
36 Vail A, Gardener E. Common statistical errors in the design and analysis of subfertility trials. Hum Reprod. 2003;18(5):1000-4. [pmid: 12721176].
37 Buck Louis GM, Schisterman EF, Dukic VM, et al. Research hurdles complicating the analysis of infertility treatment and child health. Hum Reprod. 2005;20(1):12-8. [pmid: 15489239].
38 Wang C, Chung M, Lichtenstein A, et al. Effects of Omega-3 Fatty Acids on Cardiovascular Disease. Evidence Report/Technology Assessment No. 94 (Prepared by Tufts-New England Medical Center Evidence-based Practice Center, under Contract No. 290-02-0022). AHRQ Publication No. 04-E009-2. Rockville, MD: Agency for Healthcare Research and Quality. March 2004. Available at: www.ahcpr.gov/clinic/tp/o3cardtp.htm. Accessed 17 January 2008.
39 Jüni P, Witschi A, Bloch R, et al. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282(11):1054-60. [pmid: 10493204].
40 Hull MG. Epidemiology of infertility and polycystic ovarian disease: endocrinological and demographic studies. Gynecol Endocrinol. 1987;1(3):235-45. [pmid: 3140583].
41 Nestler JE. Metformin for the treatment of the polycystic ovary syndrome. N Engl J Med. 2008;358(1):47-54. [pmid: 18172174].
42 Ehrmann DA. Polycystic ovary syndrome. N Engl J Med. 2005;352(12):1223-36. [pmid: 15788499].
43 Clark JH, Markaverich BM. The agonistic-antagonistic properties of clomiphene: a review. Pharmacol Ther. 1981;15(3):467-519. [pmid: 7048350].
44 Beck JI, Boothroyd C, Proctor M, et al. Oral anti-oestrogens and medical adjuncts for subfertility associated with anovulation [Full Review]. Cochrane Database of Systematic Reviews 2005, Issue 1. Art. No.: CD002249. DOI: 10.1002/14651858.CD002249.pub3.
45 Boostanfar R, Jain JK, Mishell DR Jr, et al. A prospective randomized trial comparing clomiphene citrate with tamoxifen citrate for ovulation induction. Fertil Steril. 2001;75(5):1024-6. 46. [pmid: 11334921].
46 Wu HH, Wang NM, Cheng ML, et al. A randomized comparison of ovulation induction and hormone profile between the aromatase inhibitor anastrozole and clomiphene citrate in women with infertility. Gynecol Endocrinol. 2007;23(2):76-81. [pmid: 17454156].
47 Bayar U, Tanriverdi HA, Barut A, et al. Letrozole vs. clomiphene citrate in patients with ovulatory infertility. Fertil Steril. 2006;85(4):1045-8. [pmid: 16580393].
48 Dehbashi S, Vafaei H, Parsanezhad MD, et al. Time of initiation of clomiphene citrate and pregnancy rate in polycystic ovarian syndrome. Int J Gynaecol Obstet. 2006;93(1):44-8. [pmid: 16530767].
49 Steiner AZ, Terplan M, Paulson RJ. Comparison of tamoxifen and clomiphene citrate for ovulation induction: a meta-analysis. Hum Reprod. 2005;20(6):1511-5. [pmid: 15845599].
50 Lord JM, Flight IHK, Norman RJ. Insulin-sensitising drugs (metformin, troglitazone, rosiglitazone, pioglitazone, D-chiro-inositol) for polycystic ovary syndrome [Full Review]. Cochrane Database of Systematic Reviews 2003, Issue 2. Art. No.: CD003053. DOI: 10.1002/14651858.CD003053.
51 Azziz R, Ehrmann D, Legro RS, et al. Troglitazone improves ovulation and hirsutism in the polycystic ovary syndrome: a multicenter, double blind, placebo-controlled trial. J Clin Endocrinol Metab. 2001;86(4):1626-32. [pmid: 11297595].
52 Sharma ST, Nestler JE. Prevention of diabetes and cardiovascular disease in women with PCOS: treatment with insulin sensitizers. Best Practice & Research Clinical Endocrinology & Metabolism. 2006;20(2):245-60. [pmid: 16772155].
53 Feig DS, Briggs GG, Koren G. Oral antidiabetic agents in pregnancy and lactation: a paradigm shift?. Ann Pharmacother. 2007;41(7):1174-80. [pmid: 17535842].
54 Fleming R, Hopkinson ZE, Wallace AM, et al. Ovarian function and metabolic factors in women with oligomenorrhea treated with metformin in a randomized double blind placebo-controlled trial. J Clin Endocrinol Metab. 2002;87(2):569-74. [pmid: 11836287].
55 Kocak M, Caliskan E, Simsir C, et al. Metformin therapy improves ovulatory rates, cervical scores, and pregnancy rates in clomiphene citrate-resistant women with polycystic ovary syndrome. Fertil Steril. 2002;77(1):101-6. [pmid: 11779598].
56 Ng EH, Wat NM, Ho PC. Effects of metformin on ovulation rate, hormonal and metabolic profiles in women with clomiphene-resistant polycystic ovaries: a randomized, double-blinded placebo-controlled trial. Hum Reprod. 2001;16(8):1625-31. [pmid: 11473953].
57 Rouzi AA, Ardawi MS. A randomized controlled trial of the efficacy of rosiglitazone and clomiphene citrate versus metformin and clomiphene citrate in women with clomiphene citrate-resistant polycystic ovary syndrome. Fertil Steril. 2006;85(2):428-35. [pmid: 16595222].
58 Ortega-Gonzalez C, Luna S, Hernandez L, et al. Responses of serum androgen and insulin resistance to metformin and pioglitazone in obese, insulin-resistant women with polycystic ovary syndrome. J Clin Endocrinol Metab. 2005;90(3):1360-5. [pmid: 15598674].
59 Palomba S, Orio F Jr, Falbo A, et al. Prospective parallel randomized, double-blind, double-dummy controlled clinical trial comparing clomiphene citrate and metformin as the first-line treatment for ovulation induction in nonobese anovulatory women with polycystic ovary syndrome. J Clin Endocrinol Metab. 2005;90(7):4068-74. [pmid: 15840746].
60 Legro RS, Barnhart HX, Schlaff WD, et al. Ovulatory response to treatment of polycystic ovary syndrome is associated with a polymorphism in the STK11 gene J Clin Endocrinol Metab. e-published November 13, 2007. doi:10.1210/jc.2007-1736 .
61 Kashyap S, Wells GA, Rosenwaks Z. Insulin-sensitizing agents as primary therapy for patients with polycystic ovarian syndrome. Hum Reprod. 2004;19(11):2474-83. [pmid: 15358717].
62 Pritts EA. Treatment of the infertile patient with polycystic ovarian syndrome. Obstet Gynecol Surv. 2002;57(9):587-97. [pmid: 12218667].
63 Kousta E, White DM, Franks S. Modern use of clomiphene citrate in induction of ovulation. Hum Reprod Update. 1997;3(4):359-65. [pmid: 9459281].
64 Casper RF, Mitwally MF. Review: aromatase inhibitors for ovulation induction. J Clin Endocrinol Metab. 2006;91(3):760-71. [pmid: 16384846].
65 Balasch J, Fabregues F, Creus M, et al. Follicular development and hormone concentrations following recombinant FSH administration for anovulation associated with polycystic ovarian syndrome: prospective, randomized comparison between low-dose step-up and modified step-down regimens. Hum Reprod. 2001;16(4):652-6. [pmid: 11278212].
66 Christin-Maitre S, Hugues JN. Recombinant FSH Study Group. A comparative randomized multicentric study comparing the step-up versus step-down protocol in polycystic ovary syndrome. Hum Reprod. 2003;18(8):1626-31. [pmid: 12871872].
67 Leader A. Monofollicular Ovulation Induction Study Group. Improved monofollicular ovulation in anovulatory or oligo-ovulatory women after a low-dose step-up protocol with weekly increments of 25 international units of follicle-stimulating hormone. Fertil Steril. 2006;85(6):1766-73. [pmid: 16759926].
68 Gerli S, Casini ML, Unfer V, et al. Ovulation induction with urinary FSH or recombinant FSH in polycystic ovary syndrome patients: a prospective randomized analysis of cost-effectiveness. Reproductive Biomedicine Online. 2004;9(5):494-9. [pmid: 15588465].
69 Revelli A, Poso F, Gennarelli G, et al. Recombinant versus highly-purified, urinary follicle-stimulating hormone (r-FSH vs. HP-uFSH) in ovulation induction: a prospective, randomized study with cost-minimization analysis. Reproductive Biology & Endocrinology. 2006;4:38. [pmid: 16848893]. [pmcid: 1550405].
70 Timmerman-van Kessel EC, Cikot RJ, Dargel-Donkers EJ, et al. A randomized controlled study comparing the endocrine effects of pulsatile intravenous gonadotropin-releasing hormone after gonadotropin-releasing hormone agonist pretreatment versus clomiphene citrate in patients with polycystic ovary syndrome. Fertil Steril. 2000;73(6):1145-8. [pmid: 10856472].
71 Nugent D, Vandekerckhove P, Hughes E, et al. Gonadotrophin therapy for ovulation induction in subfertility associated with polycystic ovary syndrome [Full Review]. Cochrane Database of Systematic Reviews 2000, Issue 3. Art. No.: CD000410. DOI: 10.1002/14651858.CD000410.
72 Bayram N, van Wely M, van der Veen F. Recombinant FSH versus urinary gonadotrophins or recombinant FSH for ovulation induction in subfertility associated with polycystic ovary syndrome [Full Review]. Cochrane Database of Systematic Reviews 2001, Issue 2. Art. No.: CD002121. DOI: 10.1002/14651858.CD002121.
73 Bayram N, van Wely M, van der Veen F. Pulsatile gonadotrophin releasing hormone for ovulation induction in subfertility associated with polycystic ovary syndrome [Full Review]. Cochrane Database of Systematic Reviews 2003, Issue 3. Art. No.: CD000412. DOI: 10.1002/14651858.CD000412.pub2.
74 Moll E, Bossuyt PM, Korevaar JC, et al. Effect of clomifene citrate plus metformin and clomifene citrate plus placebo on induction of ovulation in women with newly diagnosed polycystic ovary syndrome: randomised double blind clinical trial. BMJ. 2006;332(7556):1485. [pmid: 16769748]. [pmcid: 1482338].
75 George K, George S, Chandy A, et al. hCG administration offers no outcome benefit over spontaneous ovulation in anovulatory women treated with clomiphene citrate. Fertil Steril. 2007;87(4):985-7. [pmid: 17239866].
76 Yilmaz B, Kelekci S, Savan K, et al. Addition of human chorionic gonadotropin to clomiphene citrate ovulation induction therapy does not improve pregnancy outcomes and luteal function. Fertil Steril. 2006;85(3):783-6. [pmid: 16500364].
77 Gerli S, Gholami H, Manna C, et al. Use of ethinyl estradiol to reverse the antiestrogenic effects of clomiphene citrate in patients undergoing intrauterine insemination: a comparative, randomized study. Fertil Steril. 2000;73(1):85-9. [pmid: 10632418].
78 Unfer V, Casini ML, Costabile L, et al. High dose of phytoestrogens can reverse the antiestrogenic effects of clomiphene citrate on the endometrium in patients undergoing intrauterine insemination: a randomized trial. J Soc Gynecol Invest. 2004;11(5):323-8.
79 Ali Hassan H, El-Gezeiry D, Nafaa TM, et al. Improved responsiveness of PCOS patients to clomiphene after CYP17a inhibitor. J Assist Reprod Genet. 2001;18(11):608-11. [pmid: 11804430].
80 Malkawi HY, Qublan HS. The effect of metformin plus clomiphene citrate on ovulation and pregnancy rates in clomiphene-resistant women with polycystic ovary syndrome. Saudi Medical Journal. 2002;23(6):663-6. [pmid: 12070543].
81 Vandermolen DT, Ratts VS, Evans WS, et al. Metformin increases the ovulatory rate and pregnancy rate from clomiphene citrate in patients with polycystic ovary syndrome who are resistant to clomiphene citrate alone. Fertil Steril. 2001;75(2):310-5. [pmid: 11172832].
82 Ghazeeri G, Kutteh WH, Bryer-Ash M, et al. Effect of rosiglitazone on spontaneous and clomiphene citrate-induced ovulation in women with polycystic ovary syndrome. Fertil Steril. 2003;79(3):562-6. [pmid: 12620440].
83 Yarali H, Yildiz BO, Demirol A, et al. Co-administration of metformin during rFSH treatment in patients with clomiphene citrate-resistant polycystic ovarian syndrome: a prospective randomized trial. Hum Reprod. 2002;17(2):289-94. [pmid: 11821265].
84 Palomba S, Falbo A, Orio F Jr, et al. A randomized controlled trial evaluating metformin pre-treatment and co-administration in non-obese insulin-resistant women with polycystic ovary syndrome treated with controlled ovarian stimulation plus timed intercourse or intrauterine insemination. Hum Reprod. 2005;20(10):2879-86. [pmid: 15958399].
85 Branigan EF, Estes MA. A randomized clinical trial of treatment of clomiphene citrate-resistant anovulation with the use of oral contraceptive pill suppression and repeat clomiphene citrate treatment. Am J Obstet Gynecol. 2003;188(6):1424-8. discussion 1429–30. [pmid: 12824973].
86 Rizk AY, Bedaiwy MA, Al-Inany HG. N-acetyl-cysteine is a novel adjuvant to clomiphene citrate in clomiphene citrate-resistant patients with polycystic ovary syndrome. Fertil Steril. 2005;83(2):367-70. [pmid: 15705376].
87 Elnashar A, Abdelmageed E, Fayed M, et al. Clomiphene citrate and dexamethazone in treatment of clomiphene citrate-resistant polycystic ovary syndrome: a prospective placebo-controlled study. Hum Reprod. 2006;21(7):1805-8. [pmid: 16543255].
88 George SS, George K, Irwin C, et al. Sequential treatment of metformin and clomiphene citrate in clomiphene-resistant women with polycystic ovary syndrome: a randomized, controlled trial. Hum Reprod. 2003;18(2):299-304. [pmid: 12571165].
89 Branigan EF, Estes A. Use of micro-dose human chorionic gonadotropin (hCG) after clomiphene citrate (CC) to complete folliculogenesis in previous CC-resistant anovulation. Am J Obstet Gynecol. 2005;192(6):1890-4. discussion 1894–6. [pmid: 15970844].
90 Farquhar CM. The role of ovarian surgery in polycystic ovary syndrome. Best Pract Res Clin Obstet Gynaecol. 2004;18(5):789-802. [pmid: 15380147].
91 Bayram N, van Wely M, Kaaijk EM, et al. Using an electrocautery strategy or recombinant follicle stimulating hormone to induce ovulation in polycystic ovary syndrome: randomised controlled trial. BMJ. 2004;328(7433):192. [pmid: 14739186]. [pmcid: 318481].
92 Palomba S, Orio F Jr, Nardo LG, et al. Metformin administration versus laparoscopic ovarian diathermy in clomiphene citrate-resistant women with polycystic ovary syndrome: a prospective parallel randomized double-blind placebo-controlled trial. J Clin Endocrinol Metab. 2004;89(10):4801-9. [pmid: 15472166].
93 Palomba S, Orio F Jr, Falbo A, et al. Metformin administration and laparoscopic ovarian drilling improve ovarian response to clomiphene citrate (CC) in oligo-anovulatory CC-resistant women with polycystic ovary syndrome. Clin Endocrinol (Oxf). 2005;63(6):631-5. [pmid: 16343096].
94 Farquhar CM, Williamson K, Gudex G, et al. A randomized controlled trial of laparoscopic ovarian diathermy versus gonadotropin therapy for women with clomiphene citrate-resistant polycystic ovary syndrome. Fertil Steril. 2002;78(2):404-11. [pmid: 12137881].
95 Sharma M, Kriplani A, Agarwal N. Laparoscopic bipolar versus unipolar ovarian drilling in infertile women with resistant polycystic ovarian syndrome: a pilot study. Journal of Gynecologic Surgery. 2006;22:105-11.
96 Farquhar C, Lilford RJ, Marjoribanks J, et al. Laparoscopic ‘drilling’ by diathermy or laser for ovulation induction in anovulatory polycystic ovary syndrome [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 3. Art. No.: CD001122. DOI: 10.1002/14651858.CD001122.pub3.
97 Lewis V, Queenan J Jr, Hoeger K, et al. Clomiphene citrate monitoring for intrauterine insemination timing: a randomized trial. Fertil Steril. 2006;85(2):401-6. [pmid: 16595218].
98 Kosmas IP, Tatsioni A, Fatemi HM, et al. Human chorionic gonadotropin administration vs. luteinizing monitoring for intrauterine insemination timing, after administration of clomiphene citrate: a meta-analysis. Fertil Steril. 2007;87(3):607-12. [pmid: 17173907].
99 Guzick DS, Carson SA, Coutifaris C, et al. Efficacy of superovulation and intrauterine insemination in the treatment of infertility. National Cooperative Reproductive Medicine Network. N Engl J Med. 1999;340(3):177-83. [pmid: 9895397].
100 Al-Fozan H, Al-Khadouri M, Tan SL, et al. A randomized trial of letrozole versus clomiphene citrate in women undergoing superovulation. Fertil Steril. 2004;82(6):1561-3. [pmid: 15589860].
101 Fatemi HM, Kolibianakis E, Tournaye H, et al. Clomiphene citrate versus letrozole for ovarian stimulation: a pilot study. Reproductive Biomedicine Online. 2003;7(5):543-6. [pmid: 14680546].
102 Badawy A, Baker El Nashar A, El Totongy M. Clomiphene citrate plus N-acetyl cysteine versus clomiphene citrate for augmenting ovulation in the management of unexplained infertility: a randomized double-blind controlled trial. Fertil Steril. 2006;86(3):647-50. [pmid: 16831439].
103 Al-Fadhli R, Sylvestre C, Buckett W, et al. A randomized trial of superovulation with two different doses of letrozole. Fertil Steril. 2006;85(1):161-4. [pmid: 16412748].
104 Baysoy A, Serdaroglu H, Jamal H, et al. Letrozole versus human menopausal gonadotrophin in women undergoing intrauterine insemination. Reproductive Biomedicine Online. 2006;13(2):208-12. [pmid: 16895634].
105 Dankert T, Kremer JA, Cohlen BJ, et al. A randomized clinical trial of clomiphene citrate versus low dose recombinant FSH for ovarian hyperstimulation in intrauterine insemination cycles for unexplained and male subfertility. Hum Reprod. 2007;22(3):792-7. [pmid: 17110396].
106 Hughes E, Brown J, Collins J, et al. Clomiphene citrate for unexplained subfertility in women [Full Review]. Cochrane Database of Systematic Reviews 2000, Issue 1. Art. No.: CD000057. DOI: 10.1002/14651858.CD000057.
107 Athaullah N, Proctor M, Johnson NP. Oral versus injectable ovulation induction agents for unexplained subfertility [Full Review]. Cochrane Database of Systematic Reviews 2002, Issue 3. Art. No.: CD003052. DOI: 10.1002/14651858.CD003052.
108 Cantineau AEP, Cohlen BJ, Heineman MJ. Ovarian stimulation protocols (anti-oestrogens, gonadotrophins with and without GnRH agonists/antagonists) for intrauterine insemination (IUI) in women with subfertility [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 2. Art. No.: CD005356. DOI: 10.1002/14651858.CD005356.pub2.
109 Allegra A, Marino A, Coffaro F, et al. GnRH antagonist-induced inhibition of the premature LH surge increases pregnancy rates in IUI-stimulated cycles. A prospective randomized trial. Hum Reprod. 2007;22(1):101-8. [pmid: 17032732].
110 Demirol A, Gurgan T. Comparison of different gonadotrophin preparations in intrauterine insemination cycles for the treatment of unexplained infertility: a prospective, randomized study. Hum Reprod. 2007;22(1):97-100. [pmid: 16954409].
111 Matorras R, Recio V, Corcostegui B, et al. Recombinant human FSH versus highly purified urinary FSH: a randomized study in intrauterine insemination with husbands' spermatozoa. Hum Reprod. 2000;15(6):1231-4. [pmid: 10831546].
112 Filicori M, Cognigni GE, Pocognoli P, et al. Comparison of controlled ovarian stimulation with human menopausal gonadotropin or recombinant follicle-stimulating hormone. Fertil Steril. 2003;80(2):390-7. [pmid: 12909504].
113 Gomes MK, Vieira CS, Moura MD, et al. Controlled ovarian stimulation with exclusive FSH followed by stimulation with hCG alone, FSH alone or hMG. Eur J Obstet Gynecol Reprod Biol. 2007;130(1):99-106. [pmid: 16835006].
114 International Recombinant Human Chorionic Gonadotropin Study Group. Induction of ovulation in World Health Organization group II anovulatory women undergoing follicular stimulation with recombinant human follicle-stimulating hormone: a comparison of recombinant human chorionic gonadotropin (rhCG) and urinary hCG. Fertil Steril. 2001;75(6):1111-8. [pmid: 11384635].
115 Sakhel K, Khedr M, Schwark S, et al. Comparison of urinary and recombinant human chorionic gonadotropin during ovulation induction in intrauterine insemination cycles: a prospective randomized clinical trial. Fertil Steril. 2007;87(6):1357-62. [pmid: 17433313].
116 Karlstrom PO, Bergh T, Lundkvist O. Addition of gonadotrophin-releasing hormone agonist and/or two inseminations with husband's sperm do not improve the pregnancy rate in superovulated cycles. Acta Obstet Gynecol Scand. 2000;79(1):37-42. [pmid: 10646814].
117 Gomez-Palomares JL, Julia B, Acevedo-Martin B, et al. Timing ovulation for intrauterine insemination with a GnRH antagonist. Hum Reprod. 2005;20(2):368-72. [pmid: 15567879].
118 Checa MA, Prat M, Robles A, et al. Use of gonadotropin-releasing hormone antagonists to overcome the drawbacks of intrauterine insemination on weekends. Fertil Steril. 2006;85(3):573-7. [pmid: 16500321].
119 Crosignani PG, Somigliana E. Intrauterine Insemination Study Group. Effect of GnRH antagonists in FSH mildly stimulated intrauterine insemination cycles: a multicentre randomized trial. Hum Reprod. 2007;22(2):500-5. [pmid: 17062582].
120 Perez-Medina T, Bajo-Arenas J, Salazar F, et al. Endometrial polyps and their implication in the pregnancy rates of patients undergoing intrauterine insemination: a prospective, randomized study. Hum Reprod. 2005;20(6):1632-5. [pmid: 15760959].
121 Bensdorp AJ, Cohlen BJ, Heineman MJ, et al. Intra-uterine insemination for male subfertility [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 4. Art. No.: CD000360. DOI: 10.1002/14651858.CD000360.pub4.
122 Boomsma CM, Heineman MJ, Cohlen BJ, et al. Semen preparation techniques for intrauterine insemination [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 4. Art. No.: CD004507. DOI: 10.1002/14651858.CD004507.pub3.
123 Cantineau AEP, Heineman MJ, Cohlen BJ. Single versus double intrauterine insemination (IUI) in stimulated cycles for subfertile couples [Full Review]. Cochrane Database of Systematic Reviews 2003, Issue 1. Art. No.: CD003854. DOI: 10.1002/14651858.CD003854.
124 Al-Inany H, Aboulghar M. GnRH antagonist in assisted reproduction: a Cochrane review. Hum Reprod. 2002;17(4):874-85. [pmid: 11925376].
125 Dal Prato L, Borini A, Coticchio G, et al. Half-dose depot triptorelin in pituitary suppression for multiple ovarian stimulation in assisted reproduction technology: a randomized study. Hum Reprod. 2004;19(10):2200-5. [pmid: 15271868].
126 Yim SF, Lok IH, Cheung LP, et al. Dose-finding study for the use of long-acting gonadotrophin-releasing hormone analogues prior to ovarian stimulation for IVF. Hum Reprod. 2001;16(3):492-4. [pmid: 11228217].
127 Dal Prato L, Borini A, Trevisi MR, et al. Effect of reduced dose of triptorelin at the start of ovarian stimulation on the outcome of IVF: a randomized study. Hum Reprod. 2001;16(7):1409-14. [pmid: 11425821].
128 Fabregues F, Penarrubia J, Creus M, et al. Effect of halving the daily dose of triptorelin at the start of ovarian stimulation on hormone serum levels and the outcome of in vitro fertilization. Fertil Steril. 2005;83(3):785-8. [pmid: 15749520].
129 Garcia-Velasco JA, Isaza V, Requena A, et al. High doses of gonadotrophins combined with stop versus non-stop protocol of GnRH analogue administration in low responder IVF patients: a prospective, randomized, controlled trial. Hum Reprod. 2000;15(11):2292-6. [pmid: 11056121].
130 Simons AH, Roelofs HJ, Schmoutziguer AP, et al. Early cessation of triptorelin in in vitro fertilization: a double-blind, randomized study. Fertil Steril. 2005;83(4):889-96. [pmid: 15820796].
131 Orvieto R, Kerner R, Krissi H, et al. Comparison of leuprolide acetate and triptorelin in assisted reproductive technology cycles: a prospective, randomized study. Fertil Steril. 2002;78(6):1268-71. [pmid: 12477523].
132 Dor J, Bider D, Shulman A, et al. Effects of gonadotrophin-releasing hormone agonists on human ovarian steroid secretion in vivo and in vitro-results of a prospective, randomized in-vitro fertilization study. Hum Reprod. 2000;15(6):1225-30. [pmid: 10831545].
133 Isikoglu M, Ozgur K, Oehninger S. Extension of GnRH agonist through the luteal phase to improve the outcome of intracytoplasmic sperm injection. J Reprod Med. 2007;52(7):639-44. [pmid: 17847764].
134 Ludwig M, Felberbaum RE, Devroey P, et al. Significant reduction of the incidence of ovarian hyperstimulation syndrome (OHSS) by using the LHRH antagonist Cetrorelix (Cetrotide) in controlled ovarian stimulation for assisted reproduction. Arch Gynecol Obstet. 2000;264(1):29-32. [pmid: 10985616].
135 Albano C, Felberbaum RE, Smitz J, et al. Ovarian stimulation with HMG: results of a prospective randomized phase III European study comparing the luteinizing hormone-releasing hormone (LHRH)-antagonist cetrorelix and the LHRH-agonist buserelin. European Cetrorelix Study Group. Hum Reprod. 2000;15(3):526-31. [pmid: 10686191].
136 Bahceci M, Ulug U, Ben-Shlomo I, et al. Use of a GnRH antagonist in controlled ovarian hyperstimulation for assisted conception in women with polycystic ovary disease: a randomized, prospective, pilot study. J Reprod Med. 2005;50(2):84-90. [pmid: 15755044].
137 Barmat LI, Chantilis SJ, Hurst BS, et al. A randomized prospective trial comparing gonadotropin-releasing hormone (GnRH) antagonist/recombinant follicle-stimulating hormone (rFSH) versus GnRH-agonist/rFSH in women pretreated with oral contraceptives before in vitro fertilization. Fertil Steril. 2005;83(2):321-30. [pmid: 15705369].
138 Check ML, Check JH, Choel JK, et al. Effect of antagonists vs agonists on in vitro fertilization outcome. Clin Exp Obstet Gynecol. 2004;31(4):257-9. [pmid: 15672958].
139 European and Middle East Orgalutran Study Group. Comparable clinical outcome using the GnRH antagonist ganirelix or a long protocol of the GnRH agonist triptorelin for the prevention of premature LH surges in women undergoing ovarian stimulation. Hum Reprod. 2001;16(4):644-51. [pmid: 11278211].
140 Hohmann FP, Macklon NS, Fauser BC. A randomized comparison of two ovarian stimulation protocols with gonadotropin-releasing hormone (GnRH) antagonist cotreatment for in vitro fertilization commencing recombinant follicle-stimulating hormone on cycle day 2 or 5 with the standard long GnRH agonist protocol. J Clin Endocrinol Metab. 2003;88(1):166-73. [pmid: 12519847].
141 Lee TH, Wu MY, Chen HF, et al. Ovarian response and follicular development for single-dose and multiple-dose protocols for gonadotropin-releasing hormone antagonist administration. Fertil Steril. 2005;83(6):1700-7. [pmid: 15950639].
142 Olivennes F, Belaisch-Allart J, Emperaire JC, et al. Prospective, randomized, controlled study of in vitro fertilization-embryo transfer with a single dose of a luteinizing hormone-releasing hormone (LH-RH) antagonist (cetrorelix) or a depot formula of an LH-RH agonist (triptorelin). Fertil Steril. 2000;73(2):314-20. [pmid: 10685535].
143 Sauer MV, Thornton MH 2nd, Schoolcraft W, et al. Comparative efficacy and safety of cetrorelix with or without mid-cycle recombinant LH and leuprolide acetate for inhibition of premature LH surges in assisted reproduction. Reproductive Biomedicine Online. 2004;9(5):487-93. [pmid: 15588464].
144 Vlaisavljevic V, Reljic M, Lovrec VG, et al. Comparable effectiveness using flexible single-dose GnRH antagonist (cetrorelix) and single-dose long GnRH agonist (goserelin) protocol for IVF cycles—a prospective, randomized study. Reproductive Biomedicine Online. 2003;7(3):301-8. [pmid: 14653888].
145 Borm G, Mannaerts B. Treatment with the gonadotrophin-releasing hormone antagonist ganirelix in women undergoing ovarian stimulation with recombinant follicle stimulating hormone is effective, safe and convenient: results of a controlled, randomized, multicentre trial. The European Orgalutran Study Group [erratum appears in Hum Reprod 2000 Aug;15(8):1877]. Hum Reprod. 2000;15(7):1490-8. [pmid: 10875855].
146 Loutradis D, Stefanidis K, Drakakis P, et al. A modified gonadotropin-releasing hormone (GnRH) antagonist protocol failed to increase clinical pregnancy rates in comparison with the long GnRH protocol. Fertil Steril. 2004;82(5):1446-8. [pmid: 15533377].
147 Zikopoulos K, Kaponis A, Adonakis G, et al. A prospective randomized study comparing gonadotropin-releasing hormone agonists or gonadotropin-releasing hormone antagonists in couples with unexplained infertility and/or mild oligozoospermia. Fertil Steril. 2005;83(5):1354-62. [pmid: 15866569].
148 Fluker M, Grifo J, Leader A, et al. Efficacy and safety of ganirelix acetate versus leuprolide acetate in women undergoing controlled ovarian hyperstimulation. Fertil Steril. 2001;75(1):38-45. [pmid: 11163814].
149 Weigert M, Krischker U, Pohl M, et al. Comparison of stimulation with clomiphene citrate in combination with recombinant follicle-stimulating hormone and recombinant luteinizing hormone to stimulation with a gonadotropin-releasing hormone agonist protocol: a prospective, randomized study. Fertil Steril. 2002;78(1):34-9. [pmid: 12095487].
150 Hwang JL, Seow KM, Lin YH, et al. Ovarian stimulation by concomitant administration of cetrorelix acetate and HMG following Diane-35 pre-treatment for patients with polycystic ovary syndrome: a prospective randomized study. Hum Reprod. 2004;19(9):1993-2000. [pmid: 15284212].
151 Rombauts L, Healy D, Norman RJ, et al. A comparative randomized trial to assess the impact of oral contraceptive pretreatment on follicular growth and hormone profiles in GnRH antagonist-treated patients [erratum appears in Hum Reprod. 2006 Nov;21(11):3032]. Hum Reprod. 2006;21(1):95-103. [pmid: 16253978].
152 Huirne JA, van Loenen AC, Donnez J, et al. Effect of an oral contraceptive pill on follicular development in IVF/ICSI patients receiving a GnRH antagonist: a randomized study. Reproductive Biomedicine Online. 2006;13(2):235-45. [pmid: 16895639].
153 Kolibianakis EM, Papanikolaou EG, Camus M, et al. Effect of oral contraceptive pill pretreatment on ongoing pregnancy rates in patients stimulated with GnRH antagonists and recombinant FSH for IVF. A randomized controlled trial. Hum Reprod. 2006;21(2):352-7. [pmid: 16269449].
154 Wilcox J, Potter D, Moore M, et al. Prospective, randomized trial comparing cetrorelix acetate and ganirelix acetate in a programmed, flexible protocol for premature luteinizing hormone surge prevention in assisted reproductive technologies. Fertil Steril. 2005;84(1):108-17. [pmid: 16009165].
155 Escudero E, Bosch E, Crespo J, et al. Comparison of two different starting multiple dose gonadotropin-releasing hormone antagonist protocols in a selected group of in vitro fertilization-embryo transfer patients. Fertil Steril. 2004;81(3):562-6. [pmid: 15037403].
156 Mochtar MH. Dutch Ganirelix Study Group. The effect of an individualized GnRH antagonist protocol on folliculogenesis in IVF/ICSI. Hum Reprod. 2004;19(8):1713-8. [pmid: 15229205].
157 Cheung LP, Lam PM, Lok IH, et al. GnRH antagonist versus long GnRH agonist protocol in poor responders undergoing IVF: a randomized controlled trial. Hum Reprod. 2005;20(3):616-21. [pmid: 15608037].
158 Malmusi S, La Marca A, Giulini S, et al. Comparison of a gonadotropin-releasing hormone (GnRH) antagonist and GnRH agonist flare-up regimen in poor responders undergoing ovarian stimulation. Fertil Steril. 2005;84(2):402-6. [pmid: 16084881].
159 Marci R, Caserta D, Dolo V, et al. GnRH antagonist in IVF poor-responder patients: results of a randomized trial. Reproductive Biomedicine Online. 2005;11(2):189-93. [pmid: 16168215].
160 De Placido G, Mollo A, Clarizia R, et al. Gonadotropin-releasing hormone (GnRH) antagonist plus recombinant luteinizing hormone vs. a standard GnRH agonist short protocol in patients at risk for poor ovarian response. Fertil Steril. 2006;85(1):247-50. [pmid: 16412769].
161 Sbracia M, Farina A, Poverini R, et al. Short versus long gonadotropin-releasing hormone analogue suppression protocols for superovulation in patients > or = 40 years old undergoing intracytoplasmic sperm injection. Fertil Steril. 2005;84(3):644-8. [pmid: 16169397].
162 Pabuccu R, Onalan G, Kaya C. GnRH agonist and antagonist protocols for stage I–II endometriosis and endometrioma in in vitro fertilization/intracytoplasmic sperm injection cycles. Fertil Steril. 2007;88(4):832-9. [pmid: 17428479].
163 Albuquerque LE, Saconato H, Maciel MC. Depot versus daily administration of gonadotrophin releasing hormone agonist protocols for pituitary desensitization in assisted reproduction cycles [Full Review]. Cochrane Database of Systematic Reviews 2005, Issue 1. Art. No.: CD002808. DOI: 10.1002/14651858.CD002808.pub2.
164 Shanbhag S, Aucott L, Bhattacharya S, et al. Interventions for ‘poor responders’ to controlled ovarian hyperstimulation (COH) in in-vitro fertilisation (IVF) [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 1. Art. No.: CD004379. DOI: 10.1002/14651858.CD004379.pub2.
165 Mochtar MH, Van der Veen F, Ziech M, et al. Recombinant Luteinizing Hormone (rLH) for controlled ovarian hyperstimulation in assisted reproductive cycles [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 2. Art. No.: CD005070. DOI: 10.1002/14651858.CD005070.pub2.
166 Popovic-Todorovic B, Loft A, Bredkjaeer HE, et al. A prospective randomized clinical trial comparing an individual dose of recombinant FSH based on predictive factors versus a ‘standard’ dose of 150 IU/day in ‘standard’ patients undergoing IVF/ICSI treatment. Hum Reprod. 2003;18(11):2275-82. [pmid: 14585873].
167 Pacchiarotti A, Aragona C, Gaglione R, et al. Efficacy of a combined protocol of urinary and recombinant follicle-stimulating hormone used for ovarian stimulation of patients undergoing ICSI cycle. J Assist Reprod Genet. 2007;24(9):400-5. [pmid: 17653846].
168 European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone. Efficacy and safety of highly purified menotropin versus recombinant follicle-stimulating hormone in in vitro fertilization/intracytoplasmic sperm injection cycles: a randomized, comparative trial. Fertil Steril 2002;78(3):520–8.
169 Andersen AN, Devroey P, Arce JC. Clinical outcome following stimulation with highly purified hMG or recombinant FSH in patients undergoing IVF: a randomized assessor-blind controlled trial. Hum Reprod. 2006;21(12):3217-27. [pmid: 16873892].
170 Westergaard LG, Erb K, Laursen SB, et al. Human menopausal gonadotropin versus recombinant follicle-stimulating hormone in normogonadotropic women down-regulated with a gonadotropin-releasing hormone agonist who were undergoing in vitro fertilization and intracytoplasmic sperm injection: a prospective randomized study. Fertil Steril. 2001;76(3):543-9. [pmid: 11532479].
171 Gordon UD, Harrison RF, Fawzy M, et al. A randomized prospective assessor-blind evaluation of luteinizing hormone dosage and in vitro fertilization outcome. Fertil Steril. 2001;75(2):324-31. [pmid: 11172834].
172 Ng EH, Lau EY, Yeung WS, et al. HMG is as good as recombinant human FSH in terms of oocyte and embryo quality: a prospective randomized trial. Hum Reprod. 2001;16(2):319-25. [pmid: 11157827].
173 Strehler E, Abt M, El-Danasouri I, et al. Impact of recombinant follicle-stimulating hormone and human menopausal gonadotropins on in vitro fertilization outcome. Fertil Steril. 2001;75(2):332-6. [pmid: 11172835].
174 Dickey RP, Nichols JE, Steinkampf MP, et al. Highly purified human-derived follicle-stimulating hormone (Bravelle) has equivalent efficacy to follitropin-beta (Follistim) in infertile women undergoing in vitro fertilization. Reproductive Biology & Endocrinology. 2003;1(1):63. [pmid: 14609434]. [pmcid: 270000].
175 Kilani Z, Dakkak A, Ghunaim S, et al. A prospective, randomized, controlled trial comparing highly purified hMG with recombinant FSH in women undergoing ICSI: ovarian response and clinical outcomes. Hum Reprod. 2003;18(6):1194-9. [pmid: 12773445].
176 Schats R, Sutter PD, Bassil S, et al. Ovarian stimulation during assisted reproduction treatment: a comparison of recombinant and highly purified urinary human FSH. On behalf of The Feronia and Apis study group. Hum Reprod. 2000;15(8):1691-7. [pmid: 10920087].
177 Selman HA, De Santo M, Sterzik K, et al. Effect of highly purified urinary follicle-stimulating hormone on oocyte and embryo quality. Fertil Steril. 2002;78(5):1061-7. [pmid: 12413994].
178 Frydman R, Howles CM, Truong F. A double-blind, randomized study to compare recombinant human follicle stimulating hormone (FSH; Gonal-F) with highly purified urinary FSH (Metrodin) HP) in women undergoing assisted reproductive techniques including intracytoplasmic sperm injection. The French Multicentre Trialists. Hum Reprod. 2000;15(3):520-5. [pmid: 10686190].
179 Mohamed MA, Sbracia M, Pacchiarotti A, et al. Urinary follicle-stimulating hormone (FSH) is more effective than recombinant FSH in older women in a controlled randomized study. Fertil Steril. 2006;85(5):1398-403. [pmid: 16600226].
180 Moon SY, Choi YS, Ku SY, et al. Comparison of the efficacy and safety of a new recombinant human follicle-stimulating hormone (DA-3801) with follitropin-alpha (Gonal-F) in women undergoing controlled ovarian hyperstimulation for assisted reproductive technology. J Obstet Gynaecol Res. 2007;33(3):305-15. [pmid: 17578360].
181 Humaidan P, Bungum M, Bungum L, et al. Effects of recombinant LH supplementation in women undergoing assisted reproduction with GnRH agonist down-regulation and stimulation with recombinant FSH: an opening study. Reproductive Biomedicine Online. 2004;8(6):635-43. [pmid: 15169576].
182 Marrs R, Meldrum D, Muasher S, et al. Randomized trial to compare the effect of recombinant human FSH (follitropin alfa) with or without recombinant human LH in women undergoing assisted reproduction treatment. Reproductive Biomedicine Online. 2004;8(2):175-82. [pmid: 14989794].
183 Tarlatzis B, Tavmergen E, Szamatowicz M, et al. The use of recombinant human LH (lutropin alfa) in the late stimulation phase of assisted reproduction cycles: a double-blind, randomized, prospective study. Hum Reprod. 2006;21(1):90-4. [pmid: 16172149].
184 Koichi K, Yukiko N, Shima K, et al. Efficacy of low-dose human chorionic gonadotropin (hCG) in a GnRH antagonist protocol. J Assist Reprod Genet. 2006;23(5):223-8. [pmid: 16786420].
185 Griesinger G, Schultze-Mosgau A, Dafopoulos K, et al. Recombinant luteinizing hormone supplementation to recombinant follicle-stimulating hormone induced ovarian hyperstimulation in the GnRH-antagonist multiple-dose protocol. Hum Reprod. 2005;20(5):1200-6. [pmid: 15665010].
186 Levi-Setti PE, Cavagna M, Bulletti C. Recombinant gonadotrophins associated with GnRH antagonist (cetrorelix) in ovarian stimulation for ICSI: comparison of r-FSH alone and in combination with r-LH. Eur J Obstet Gynecol Reprod Biol. 2006;126(2):212-6. [pmid: 16377062].
187 Serafini P, Yadid I, Motta EL, et al. Ovarian stimulation with daily late follicular phase administration of low-dose human chorionic gonadotropin for in vitro fertilization: a prospective, randomized trial. Fertil Steril. 2006;86(4):830-8. [pmid: 16963040].
188 Drakakis P, Loutradis D, Kallianidis K, et al. Small doses of LH activity are needed early in ovarian stimulation for better quality oocytes in IVF-ET. Eur J Obstet Gynecol Reprod Biol. 2005;121(1):77-80. [pmid: 15989987].
189 Balasch J, Creus M, Fabregues F, et al. The effect of exogenous luteinizing hormone (LH) on oocyte viability: evidence from a comparative study using recombinant human follicle-stimulating hormone (FSH) alone or in combination with recombinant LH for ovarian stimulation in pituitary-suppressed women undergoing assisted reproduction. J Assist Reprod Genet. 2001;18(5):250-6. [pmid: 11464575].
190 Aboulghar MA, Mansour RT, Serour GI, et al. Increasing the dose of human menopausal gonadotrophins on day of GnRH antagonist administration: randomized controlled trial. Reproductive Biomedicine Online. 2004;8(5):524-7. [pmid: 15151713].
191 Klinkert ER, Broekmans FJ, Looman CW, et al. Expected poor responders on the basis of an antral follicle count do not benefit from a higher starting dose of gonadotrophins in IVF treatment: a randomized controlled trial. Hum Reprod. 2005;20(3):611-5. [pmid: 15591079].
192 Out HJ, Rutherford A, Fleming R, et al. A randomized, double-blind, multicentre clinical trial comparing starting doses of 150 and 200 IU of recombinant FSH in women treated with the GnRH antagonist ganirelix for assisted reproduction. Hum Reprod. 2004;19(1):90-5. [pmid: 14688163].
193 Hoomans EH, Mulder BB. Asian Purgeon Study Group. A group-comparative, randomized, double-blind comparison of the efficacy and efficiency of two fixed daily dose regimens (100- and 200-IU) of recombinant follicle stimulating hormone (rFSH, Puregon) in Asian women undergoing ovarian stimulation for IVF/ICSI. J Assist Reprod Genet. 2002;19(10):470-6. [pmid: 12416651].
194 Ng EY, Yeung WS, Ho PC. Comparison of two dosages of recombinant human follicle-stimulating hormone in Chinese women undergoing controlled ovarian stimulation: prospective randomised double-blind study. Hong Kong Medical Journal. 2000;6(4):368-74. [pmid: 11177158].
195 Latin-American Puregon IVF Study Group. A double-blind clinical trial comparing a fixed daily dose of 150 and 250 IU of recombinant follicle-stimulating hormone in women undergoing in vitro fertilization. Fertil Steril. 2001;76(5):950-6. [pmid: 11704116].
196 Hugues JN, Barlow DH, Rosenwaks Z, et al. Improvement in consistency of response to ovarian stimulation with recombinant human follicle stimulating hormone resulting from a new method for calibrating the therapeutic preparation. Reproductive Biomedicine Online. 2003;6(2):185-90. [pmid: 12675998].
197 Propst AM, Bates GW, Robinson RD, et al. A randomized controlled trial of increasing recombinant follicle-stimulating hormone after initiating a gonadotropin-releasing hormone antagonist for in vitro fertilization-embryo transfer. Fertil Steril. 2006;86(1):58-63. [pmid: 16753156].
198 Scholtes MC, Schnittert B, van Hoogstraten D, et al. A comparison of 3-day and daily follicle-stimulating hormone injections on stimulation days 1–6 in women undergoing controlled ovarian hyperstimulation. Fertil Steril. 2004;81(4):996-1001. [pmid: 15066454].
199 Greco E, Polonio-Balbi P, Ferrero S, et al. Use of a fully automated injector for self-administration of follitropin alpha in an IVF/ICSI programme. Reproductive Biomedicine Online. 2005;11(4):415-20. [pmid: 16274597].
200 Platteau P, Laurent E, Albano C, et al. An open, randomized single-centre study to compare the efficacy and convenience of follitropin beta administered by a pen device with follitropin alpha administered by a conventional syringe in women undergoing ovarian stimulation for IVF/ICSI. Hum Reprod. 2003;18(6):1200-4. [pmid: 12773446].
201 Gomez-Palomares JL, Acevedo-Martin B, Andres L, et al. LH improves early follicular recruitment in women over 38 years old [erratum appears in Reprod Biomed Online. 2006 Jan;12(1):132]. Reproductive Biomedicine Online. 2005;11(4):409-14. [pmid: 16274596].
202 De Placido G, Alviggi C, Perino A, et al. Recombinant human LH supplementation versus recombinant human FSH (rFSH) step-up protocol during controlled ovarian stimulation in normogonadotrophic women with initial inadequate ovarian response to rFSH. A multicentre, prospective, randomized controlled trial. Hum Reprod. 2005;20(2):390-6. [pmid: 15576390].
203 De Placido G, Mollo A, Alviggi C, et al. Rescue of IVF cycles by HMG in pituitary down-regulated normogonadotrophic young women characterized by a poor initial response to recombinant FSH. Hum Reprod. 2001;16(9):1875-9. [pmid: 11527891].
204 Fabregues F, Creus M, Penarrubia J, et al. Effects of recombinant human luteinizing hormone supplementation on ovarian stimulation and the implantation rate in down-regulated women of advanced reproductive age. Fertil Steril. 2006;85(4):925-31. [pmid: 16580376].
205 Van Wely M, Westergaard LG, Bossuyt PMM, et al. Human menopausal gonadotropin versus recombinant follicle stimulation hormone for ovarian stimulation in assisted reproductive cycles [Full Review]. Cochrane Database of Systematic Reviews 2003, Issue 1. Art. No.: CD003973. DOI: 10.1002/14651858.CD003973.
206 Al-Inany HG, Aboulghar M, Mansour R, et al. Recombinant versus urinary human chorionic gonadotrophin for ovulation induction in assisted conception [Full Review]. Cochrane Database of Systematic Reviews 2005, Issue 2. Art. No.: CD003719. DOI: 10.1002/14651858.CD003719.pub2.
207 Kolibianakis EM, Albano C, Camus M, et al. Prolongation of the follicular phase in in vitro fertilization results in a lower ongoing pregnancy rate in cycles stimulated with recombinant follicle-stimulating hormone and gonadotropin-releasing hormone antagonists. Fertil Steril. 2004;82(1):102-7. [pmid: 15236997].
208 European Recombinant Human Chorionic Gonadotrophin Study Group. Induction of final follicular maturation and early luteinization in women undergoing ovulation induction for assisted reproduction treatment—recombinant HCG versus urinary HCG. The European Recombinant Human Chorionic Gonadotrophin Study Group. Hum Reprod. 2000;15(7):1446-51. [pmid: 10875887].
209 Driscoll GL, Tyler JP, Hangan JT, et al. A prospective, randomized, controlled, double-blind, double-dummy comparison of recombinant and urinary HCG for inducing oocyte maturation and follicular luteinization in ovarian stimulation. Hum Reprod. 2000;15(6):1305-10. [pmid: 10831560].
210 Chang P, Kenley S, Burns T, et al. Recombinant human chorionic gonadotropin (rhCG) in assisted reproductive technology: results of a clinical trial comparing two doses of rhCG (Ovidrel) to urinary hCG (Profasi) for induction of final follicular maturation in in vitro fertilization-embryo transfer. Fertil Steril. 2001;76(1):67-74. [pmid: 11438321].
211 European Recombinant LH Study Group. Human recombinant luteinizing hormone is as effective as, but safer than, urinary human chorionic gonadotropin in inducing final follicular maturation and ovulation in in vitro fertilization procedures: results of a multicenter double-blind study. J Clin Endocrinol Metab. 2001;86(6):2607-18. [pmid: 11397861].
212 Manau D, Fabregues F, Arroyo V, et al. Hemodynamic changes induced by urinary human chorionic gonadotropin and recombinant luteinizing hormone used for inducing final follicular maturation and luteinization. Fertil Steril. 2002;78(6):1261-7. [pmid: 12477522].
213 Humaidan P, Bredkjaer HE, Bungum L, et al. GnRH agonist (buserelin) or hCG for ovulation induction in GnRH antagonist IVF/ICSI cycles: a prospective randomized study. Hum Reprod. 2005;20(5):1213-20. [pmid: 15760966].
214 Humaidan P, Bungum L, Bungum M, et al. Rescue of corpus luteum function with peri-ovulatory HCG supplementation in IVF/ICSI GnRH antagonist cycles in which ovulation was triggered with a GnRH agonist: a pilot study. Reproductive Biomedicine Online. 2006;13(2):173-8. [pmid: 16895629].
215 Kolibianakis EM, Schultze-Mosgau A, Schroer A, et al. A lower ongoing pregnancy rate can be expected when GnRH agonist is used for triggering final oocyte maturation instead of HCG in patients undergoing IVF with GnRH antagonists. Hum Reprod. 2005;20(10):2887-92. [pmid: 15979994].
216 Engmann L, DiLuigi A, Schmidt D, et al. The use of gonadotropin-releasing hormone (GnRH) agonist to induce oocyte maturation after cotreatment with GnRH antagonist in high-risk patients undergoing in vitro fertilization prevents the risk of ovarian hyperstimulation syndrome: a prospective randomized controlled study. Fertil Steril. 2008;89(1):84-91. [pmid: 17462639].
217 Branigan EF, Estes A, Walker K, et al. Thorough sonographic oocyte retrieval during in vitro fertilization produces results similar to ovarian wedge resection in patients with clomiphene citrate-resistant polycystic ovarian syndrome. Am J Obstet Gynecol. 2006;194(6):1696-700. discussion 1700–1. [pmid: 16731088].
218 Humaidan P, Stener-Victorin E. Pain relief during oocyte retrieval with a new short duration electro-acupuncture technique—an alternative to conventional analgesic methods. Hum Reprod. 2004;19(6):1367-72. [pmid: 15105387].
219 Ng EH, Chui DK, Tang OS, et al. Paracervical block with and without conscious sedation: a comparison of the pain levels during egg collection and the postoperative side effects. Fertil Steril. 2001;75(4):711-7. [pmid: 11287024].
220 Lok IH, Chan MT, Chan DL, et al. A prospective randomized trial comparing patient-controlled sedation using propofol and alfentanil and physician-administered sedation using diazepam and pethidine during transvaginal ultrasound-guided oocyte retrieval. Hum Reprod. 2002;17(8):2101-6. [pmid: 12151444].
221 Cerne A, Bergh C, Borg K, et al. Pre-ovarian block versus paracervical block for oocyte retrieval. Hum Reprod. 2006;21(11):2916-21. [pmid: 16840798].
222 Humaidan P, Brock K, Bungum L, et al. Pain relief during oocyte retrieval—exploring the role of different frequencies of electro-acupuncture. Reproductive Biomedicine Online. 2006;13(1):120-5. [pmid: 16820123].
223 Stener-Victorin E, Waldenstrom U, Wikland M, et al. Electro-acupuncture as a peroperative analgesic method and its effects on implantation rate and neuropeptide Y concentrations in follicular fluid. Hum Reprod. 2003;18(7):1454-60. [pmid: 12832372].
224 Thompson N, Murray S, MacLennan F, et al. A randomised controlled trial of intravenous versus inhalational analgesia during outpatient oocyte recovery. Anaesthesia. 2000;55(8):770-3. [pmid: 10947691].
225 Kwan I, Bhattacharya S, Knox F, et al. Conscious sedation and analgesia for oocyte retrieval during in vitro fertilisation procedures [Full Review]. Cochrane Database of Systematic Reviews 2005, Issue 3. Art. No.: CD004829. DOI: 10.1002/14651858.CD004829.pub2.
226 Dal Prato L, Borini A, Cattoli M, et al. Endometrial preparation for frozen-thawed embryo transfer with or without pretreatment with gonadotropin-releasing hormone agonist. Fertil Steril. 2002;77(5):956-60. [pmid: 12009350].
227 El-Toukhy T, Taylor A, Khalaf Y, et al. Pituitary suppression in ultrasound-monitored frozen embryo replacement cycles. A randomised study. Hum Reprod. 2004;19(4):874-9. [pmid: 15016780].
228 Wright KP, Guibert J, Weitzen S, et al. Artificial versus stimulated cycles for endometrial preparation prior to frozen-thawed embryo transfer. Reproductive Biomedicine Online. 2006;13(3):321-5. [pmid: 16984757].
229 Ghobara T, Vandekerckhove P. Cycle regimens for frozen-thawed embryo transfer [Full Review]. Cochrane Database of Systematic Reviews 2008, Issue 1. Art. No.: CD003414. DOI: 10.1002/14651858.CD003414.pub2.
230 Berkkanoglu M, Isikoglu M, Seleker M, et al. Flushing the endometrium prior to the embryo transfer does not affect the pregnancy rate. Reproductive Biomedicine Online. 2006;13(2):268-71. [pmid: 16895645].
231 Bjuresten K, Hreinsson JG, Fridstrom M, et al. Embryo transfer by midwife or gynecologist: a prospective randomized study. Acta Obstet Gynecol Scand. 2003;82(5):462-6. [pmid: 12752077].
232 Brook N, Khalaf Y, Coomarasamy A, et al. A randomized controlled trial of prophylactic antibiotics (co-amoxiclav) prior to embryo transfer. Hum Reprod. 2006;21(11):2911-5. [pmid: 16832124].
233 Rhodes TL, Higdon HL 3rd, Boone WR. Comparison of pregnancy rates for two embryo-transfer catheters. Fertil Steril. 2007;87(2):411-6. [pmid: 17094973].
234 McIlveen M, Lok FD, Pritchard J, et al. Modern embryo transfer catheters and pregnancy outcome: a prospective randomized trial. Fertil Steril. 2005;84(4):996-1000. [pmid: 16213855].
235 van Weering HG, Schats R, McDonnell J, et al. The impact of the embryo transfer catheter on the pregnancy rate in IVF. Hum Reprod. 2002;17(3):666-70. [pmid: 11870120].
236 Martinez F, Coroleu B, Parriego M, et al. Ultrasound-guided embryo transfer: immediate withdrawal of the catheter versus a 30 second wait. Hum Reprod. 2001;16(5):871-4. [pmid: 11331631].
237 Friedler S, Schachter M, Strassburger D, et al. A randomized clinical trial comparing recombinant hyaluronan/recombinant albumin versus human tubal fluid for cleavage stage embryo transfer in patients with multiple IVF-embryo transfer failure. Hum Reprod. 2007;22(9):2444-8. [pmid: 17644629].
238 Korosec S, Virant-Klun I, Tomazevic T, et al. Single fresh and frozen-thawed blastocyst transfer using hyaluronan-rich transfer medium. Reproductive Biomedicine Online. 2007;15(6):701-7. [pmid: 18062869].
239 Mahani IM, Davar R. Hyaluronic acid versus albumin in human embryo transfer medium. Eastern Mediterranean Health Journal. 2007;13(4):876-80. [pmid: 17955771].
240 Kosmas IP, Janssens R, De Munck L, et al. Ultrasound-guided embryo transfer does not offer any benefit in clinical outcome: a randomized controlled trial. Hum Reprod. 2007;22(5):1327-34. [pmid: 17289683].
241 Coroleu B, Carreras O, Veiga A, et al. Embryo transfer under ultrasound guidance improves pregnancy rates after in-vitro fertilization. Hum Reprod. 2000;15(3):616-20. [pmid: 10686207].
242 de Camargo Martins AM, Baruffi RL, Mauri AL, et al. Ultrasound guidance is not necessary during easy embryo transfers. J Assist Reprod Genet. 2004;21(12):421-5. [pmid: 15704516].
243 Li R, Lu L, Hao G, et al. Abdominal ultrasound-guided embryo transfer improves clinical pregnancy rates after in vitro fertilization: experiences from 330 clinical investigations. J Assist Reprod Genet. 2005;22(1):3-8. [pmid: 15807215].
244 Matorras R, Urquijo E, Mendoza R, et al. Ultrasound-guided embryo transfer improves pregnancy rates and increases the frequency of easy transfers. Hum Reprod. 2002;17(7):1762-6. [pmid: 12093836].
245 Coroleu B, Barri PN, Carreras O, et al. Effect of using an echogenic catheter for ultrasound-guided embryo transfer in an IVF programme: a prospective, randomized, controlled study. Hum Reprod. 2006;21(7):1809-15. [pmid: 16556674].
246 Coroleu B, Barri PN, Carreras O, et al. The usefulness of ultrasound guidance in frozen-thawed embryo transfer: a prospective randomized clinical trial. Hum Reprod. 2002;17(11):2885-90. [pmid: 12407044].
247 Tang OS, Ng EH, So WW, et al. Ultrasound-guided embryo transfer: a prospective randomized controlled trial. Hum Reprod. 2001;16(11):2310-5. [pmid: 11679510].
248 Brown JA, Buckingham K, Abou-Setta A, et al. Ultrasound versus ‘clinical touch’ for catheter guidance during embryo transfer in women [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 1. Art. No.: CD006107. DOI: 10.1002/14651858.CD006107.pub2.
249 Daya S, Gunby J. Luteal phase support in assisted reproduction cycles [Full Review]. Cochrane Database of Systematic Reviews 2004, Issue 3. Art. No.: CD004830. DOI: 10.1002/14651858.CD004830.
250 Propst AM, Hill JA, Ginsburg ES, et al. A randomized study comparing Crinone 8% and intramuscular progesterone supplementation in in vitro fertilization-embryo transfer cycles. Fertil Steril. 2001;76(6):1144-9. [pmid: 11730742].
251 Unfer V, Casini ML, Costabile L, et al. 17 alpha-hydroxyprogesterone caproate versus intravaginal progesterone in IVF-embryo transfer cycles: a prospective randomized study. Reproductive Biomedicine Online. 2004;9(1):17-21. [pmid: 15257811].
252 Chakravarty BN, Shirazee HH, Dam P, et al. Oral dydrogesterone versus intravaginal micronised progesterone as luteal phase support in assisted reproductive technology (ART) cycles: results of a randomised study. Journal of Steroid Biochemistry & Molecular Biology. 2005;97(5):416-20. [pmid: 16213136].
253 Kleinstein J. Luteal Phase Study Group. Efficacy and tolerability of vaginal progesterone capsules (Utrogest 200) compared with progesterone gel (Crinone 8%) for luteal phase support during assisted reproduction. Fertil Steril. 2005;83(6):1641-9. [pmid: 15950631].
254 Geber S, Moreira AC, de Paula SO, et al. Comparison between two forms of vaginally administered progesterone for luteal phase support in assisted reproduction cycles. Reproductive Biomedicine Online. 2007;14(2):155-8. [pmid: 17298716].
255 Ludwig M, Schwartz P, Babahan B, et al. Luteal phase support using either Crinone 8% or Utrogest: results of a prospective, randomized study. Eur J Obstet Gynecol Reprod Biol. 2002;103(1):48-52. [pmid: 12039463].
256 Tay PY, Lenton EA. The impact of luteal supplement on pregnancy outcome following stimulated IVF cycles. Med J Malaysia. 2005;60(2):151-7. [pmid: 16114155].
257 Zegers-Hochschild F, Balmaceda JP, Fabres C, et al. Prospective randomized trial to evaluate the efficacy of a vaginal ring releasing progesterone for IVF and oocyte donation. Hum Reprod. 2000;15(10):2093-7. [pmid: 11006179].
258 Ng EH, Miao B, Cheung W, et al. A randomised comparison of side effects and patient inconvenience of two vaginal progesterone formulations used for luteal support in in vitro fertilisation cycles. Eur J Obstet Gynecol Reprod Biol. 2003;111(1):50-4. [pmid: 14557011].
259 Beckers NG, Laven JS, Eijkemans MJ, et al. Follicular and luteal phase characteristics following early cessation of gonadotrophin-releasing hormone agonist during ovarian stimulation for in-vitro fertilization. Hum Reprod. 2000;15(1):43-9. [pmid: 10611186].
260 Ludwig M, Finas A, Katalinic A, et al. Prospective, randomized study to evaluate the success rates using hCG, vaginal progesterone or a combination of both for luteal phase support. Acta Obstet Gynecol Scand. 2001;80(6):574-82. [pmid: 11380297].
261 Vimpeli T, Tinkanen H, Huhtala H, et al. Salivary and serum progesterone concentrations during two luteal support regimens used in in vitro fertilization treatment. Fertil Steril. 2001;76(4):847-8. [pmid: 11680432].
262 Martinez F, Coroleu B, Parera N, et al. Human chorionic gonadotropin and intravaginal natural progesterone are equally effective for luteal phase support in IVF. Gynecol Endocrinol. 2000;14(5):316-20. [pmid: 11109970].
263 Nyboe Andersen A, Popovic-Todorovic B, Schmidt KT, et al. Progesterone supplementation during early gestations after IVF or ICSI has no effect on the delivery rates: a randomized controlled trial. Hum Reprod. 2002;17(2):357-61. [pmid: 11821278].
264 Baruffi R, Mauri AL, Petersen CG, et al. Effects of vaginal progesterone administration starting on the day of oocyte retrieval on pregnancy rates. J Assist Reprod Genet. 2003;20(12):517-20. [pmid: 15035552].
265 Mochtar MH, Van Wely M, Van der Veen F. Timing luteal phase support in GnRH agonist down-regulated IVF/embryo transfer cycles. Hum Reprod. 2006;21(4):905-8. [pmid: 16373409].
266 Williams SC, Oehninger S, Gibbons WE, et al. Delaying the initiation of progesterone supplementation results in decreased pregnancy rates after in vitro fertilization: a randomized, prospective study. Fertil Steril. 2001;76(6):1140-3. [pmid: 11730741].
267 Fujimoto A, Osuga Y, Fujiwara T, et al. Human chorionic gonadotropin combined with progesterone for luteal support improves pregnancy rate in patients with low late-midluteal estradiol levels in IVF cycles. J Assist Reprod Genet. 2002;19(12):550-4. [pmid: 12503886].
268 Unfer V, Casini ML, Gerli S, et al. Phytoestrogens may improve the pregnancy rate in in vitro fertilization-embryo transfer cycles: a prospective, controlled, randomized trial. Fertil Steril. 2004;82(6):1509-13. [pmid: 15589851].
269 Lukaszuk K, Liss J, Lukaszuk M, et al. Optimization of estradiol supplementation during the luteal phase improves the pregnancy rate in women undergoing in vitro fertilization-embryo transfer cycles. Fertil Steril. 2005;83(5):1372-6. [pmid: 15866571].
270 Tay PY, Lenton EA. Inhibition of progesterone secretion by oestradiol administered in the luteal phase of assisted conception cycles. Med J Malaysia. 2003;58(2):187-95. [pmid: 14569738].
271 Fatemi HM, Kolibianakis EM, Camus M, et al. Addition of estradiol to progesterone for luteal supplementation in patients stimulated with GnRH antagonist/rFSH for IVF: a randomized controlled trial. Hum Reprod. 2006;21(10):2628-32. [pmid: 16857887].
272 Tesarik J, Hazout A, Mendoza-Tesarik R, et al. Beneficial effect of luteal-phase GnRH agonist administration on embryo implantation after ICSI in both GnRH agonist- and antagonist-treated ovarian stimulation cycles. Hum Reprod. 2006;21(10):2572-9. [pmid: 16926261].
273 Battaglia C, Regnani G, Marsella T, et al. Adjuvant L-arginine treatment in controlled ovarian hyperstimulation: a double-blind, randomized study. Hum Reprod. 2002;17(3):659-65. [pmid: 11870119].
274 Pinheiro OL, Cavagna M, Baruffi RL, et al. Administration of beta2-adrenergic agonists during the peri-implantation period does not improve implantation or pregnancy rates in intracytoplasmic sperm injection (ICSI) cycles. J Assist Reprod Genet. 2003;20(12):513-6. [pmid: 15035551].
275 Moon HS, Park SH, Lee JO, et al. Treatment with piroxicam before embryo transfer increases the pregnancy rate after in vitro fertilization and embryo transfer. Fertil Steril. 2004;82(4):816-20. [pmid: 15482753].
276 Duvan CI, Ozmen B, Satiroglu H, et al. Does addition of low-dose aspirin and/or steroid as a standard treatment in nonselected intracytoplasmic sperm injection cycles improve in vitro fertilization success? A randomized, prospective, placebo-controlled study. J Assist Reprod Genet. 2006;23(1):15-21. [pmid: 16518579].
277 Pakkila M, Rasanen J, Heinonen S, et al. Low-dose aspirin does not improve ovarian responsiveness or pregnancy rate in IVF and ICSI patients: a randomized, placebo-controlled double-blind study. Hum Reprod. 2005;20(8):2211-4. [pmid: 15817582].
278 Ubaldi F, Rienzi L, Ferrero S, et al. Low dose prednisolone administration in routine ICSI patients does not improve pregnancy and implantation rates. Hum Reprod. 2002;17(6):1544-7. [pmid: 12042275].
279 Urman B, Mercan R, Alatas C, et al. Low-dose aspirin does not increase implantation rates in patients undergoing intracytoplasmic sperm injection: a prospective randomized study. J Assist Reprod Genet. 2000;17(10):586-90. [pmid: 11209540].
280 Cha KY, Wirth DP. Does prayer influence the success of in vitro fertilization-embryo transfer? Report of a masked, randomized trial. J Reprod Med. 2001;46(9):781-7. [pmid: 11584476].
281 Smith C, Coyle M, Norman RJ. Influence of acupuncture stimulation on pregnancy rates for women undergoing embryo transfer. Fertil Steril. 2006;85(5):1352-8. [pmid: 16600225].
282 Dieterle S, Ying G, Hatzmann W, et al. Effect of acupuncture on the outcome of in vitro fertilization and intracytoplasmic sperm injection: a randomized, prospective, controlled clinical study. Fertil Steril. 2006;85(5):1347-51. [pmid: 16616748].
283 Westergaard LG, Mao Q, Krogslund M, et al. Acupuncture on the day of embryo transfer significantly improves the reproductive outcome in infertile women: a prospective, randomized trial. Fertil Steril. 2006;85(5):1341-6. [pmid: 16600232].
284 Tremellen KP, Valbuena D, Landeras J, et al. The effect of intercourse on pregnancy rates during assisted human reproduction. Hum Reprod. 2000;15(12):2653-8. [pmid: 11098040].
285 Chan CH, Ng EH, Chan CL, et al. Effectiveness of psychosocial group intervention for reducing anxiety in women undergoing in vitro fertilization: a randomized controlled study. Fertil Steril. 2006;85(2):339-46. [pmid: 16595209].
286 Ohl J, Lefebvre-Maunoury C, Wittemer C, et al. Nitric oxide donors for patients undergoing IVF. A prospective, double-blind, randomized, placebo-controlled trial. Hum Reprod. 2002;17(10):2615-20. [pmid: 12351537].
287 Stern C, Chamley L, Norris H, et al. A randomized, double-blind, placebo-controlled trial of heparin and aspirin for women with in vitro fertilization implantation failure and antiphospholipid or antinuclear antibodies. Fertil Steril. 2003;80(2):376-83. [pmid: 12909502].
288 Stephenson MD, Fluker MR. Treatment of repeated unexplained in vitro fertilization failure with intravenous immunoglobulin: a randomized, placebo-controlled Canadian trial. Fertil Steril. 2000;74(6):1108-13. [pmid: 11119735].
289 Goswami SK, Das T, Chattopadhyay R, et al. A randomized single-blind controlled trial of letrozole as a low-cost IVF protocol in women with poor ovarian response: a preliminary report. Hum Reprod. 2004;19(9):2031-5. [pmid: 15217999].
290 Rama Raju GA, Shashi Kumari G, Krishna KM, et al. Assessment of uterine cavity by hysteroscopy in assisted reproduction programme and its influence on pregnancy outcome. Arch Gynecol Obstet. 2006;274(3):160-4. [pmid: 16715289].
291 Keay SD, Lenton EA, Cooke ID, et al. Low-dose dexamethasone augments the ovarian response to exogenous gonadotrophins leading to a reduction in cycle cancellation rate in a standard IVF programme. Hum Reprod. 2001;16(9):1861-5. [pmid: 11527889].
292 Tesarik J, Hazout A, Mendoza C. Improvement of delivery and live birth rates after ICSI in women aged >40 years by ovarian co-stimulation with growth hormone. Hum Reprod. 2005;20(9):2536-41. [pmid: 15860489].
293 Tang T, Glanville J, Orsi N, et al. The use of metformin for women with PCOS undergoing IVF treatment. Hum Reprod. 2006;21(6):1416-25. [pmid: 16501038].
294 Kjotrod SB, von During V, Carlsen SM. Metformin treatment before IVF/ICSI in women with polycystic ovary syndrome; a prospective, randomized, double blind study. Hum Reprod. 2004;19(6):1315-22. [pmid: 15117902].
295 Rickes D, Nickel I, Kropf S, et al. Increased pregnancy rates after ultralong postoperative therapy with gonadotropin-releasing hormone analogs in patients with endometriosis. Fertil Steril. 2002;78(4):757-62. [pmid: 12372452].
296 Surrey ES, Silverberg KM, Surrey MW, et al. Effect of prolonged gonadotropin-releasing hormone agonist therapy on the outcome of in vitro fertilization-embryo transfer in patients with endometriosis. Fertil Steril. 2002;78(4):699-704. [pmid: 12372443].
297 Demirol A, Guven S, Baykal C, et al. Effect of endometrioma cystectomy on IVF outcome: a prospective randomized study. Reproductive Biomedicine Online. 2006;12(5):639-43. [pmid: 16790114].
298 Kontoravdis A, Makrakis E, Pantos K, et al. Proximal tubal occlusion and salpingectomy result in similar improvement in in vitro fertilization outcome in patients with hydrosalpinx. Fertil Steril. 2006;86(6):1642-9. [pmid: 17069813].
299 Avrech OM, Orvieto R, Pinkas H, et al. Inclusion of standard and low-dose gonadotropin releasing hormone-analog (short protocol) in controlled ovarian hyperstimulation regimens in normogonadotropic patients aged 40–48 years who are undergoing in vitro fertilization. Gynecol Endocrinol. 2004;19(5):247-52. [pmid: 15726912].
300 Qublan HS, Amarin Z, Tahat YA, et al. Ovarian cyst formation following GnRH agonist administration in IVF cycles: incidence and impact. Hum Reprod. 2006;21(3):640-4. [pmid: 16253965].
301 Poustie VJ, Dodd S, Drakeley AJ. Low-dose aspirin for in vitro fertilisation [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 4. Art. No.: CD004832. DOI:10.1002/14651858.CD004832.pub2.
302 Boomsma CM, Keay SD, Macklon NS. Peri-implantation glucocorticoid administration for assisted reproductive technology cycles [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 1. Art. No.: CD005996. DOI: 10.1002/14651858.CD005996.pub2.
303 Harper K, Proctor M, Hughes E. Growth hormone for in vitro fertilization [Full Review]. Cochrane Database of Systematic Reviews 2003, Issue 3. Art. No.: CD000099. DOI: 10.1002/14651858.CD000099.
304 Sallam HN, Garcia-Velasco JA, Dias S, et al. Long-term pituitary down-regulation before in vitro fertilization (IVF) for women with endometriosis [Full Review]. Cochrane Database of Systematic Reviews 2006, Issue 1. Art. No.: CD004635. DOI: 10.1002/14651858.CD004635.pub2.
305 Johnson NP, Mak W, Sowter MC. Surgical treatment for tubal disease in women due to undergo in vitro fertilisation [Full Review]. Cochrane Database of Systematic Reviews 2004, Issue 3. Art. No.: CD002125. DOI: 10.1002/14651858.CD002125.pub2.
306 Gokmen O, Ugur M, Ekin M, et al. Intravenous albumin versus hydroxyethyl starch for the prevention of ovarian hyperstimulation in an in-vitro fertilization programme: a prospective randomized placebo controlled study. Eur J Obstet Gynecol Reprod Biol. 2001;96(2):187-92. [pmid: 11384805].
307 Bellver J, Munoz EA, Ballesteros A, et al. Intravenous albumin does not prevent moderate-severe ovarian hyperstimulation syndrome in high-risk IVF patients: a randomized controlled study. Hum Reprod. 2003;18(11):2283-8. [pmid: 14585874].
308 Aboulghar M, Evers JH, Al-Inany H. Intra-venous albumin for preventing severe ovarian hyperstimulation syndrome [Full Review]. Cochrane Database of Systematic Reviews 2002, Issue 2. Art. No.: CD001302. DOI: 10.1002/14651858.CD001302.
309 D'Angelo A, Amso N. Embryo freezing for preventing ovarian hyperstimulation syndrome [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 3. Art. No.: CD002806. DOI: 10.1002/14651858.CD002806.pub2.
310 D'Angelo A, Amso N. Coasting (withholding gonadotrophins) for preventing ovarian hyperstimulation syndrome [Full Review]. Cochrane Database of Systematic Reviews 2002, Issue 3. Art. No.: CD002811. DOI: 10.1002/14651858.CD002811.
311 Kupker W, al-Hasani S, Diedrich K. Assisted fertilization—treatment of severe male subfertility. Andrologia. 1996;28(Suppl1):37-42. [pmid: 9017095].
312 Goverde AJ, McDonnell J, Vermeiden JP, et al. Intrauterine insemination or in-vitro fertilisation in idiopathic subfertility and male subfertility: a randomised trial and cost-effectiveness analysis. Lancet. 2000;355(9197):13-8. [pmid: 10615885].
313 Bhattacharya S, Hamilton MP, Shaaban M, et al. Conventional in-vitro fertilisation versus intracytoplasmic sperm injection for the treatment of non-male-factor infertility: a randomised controlled trial. Lancet. 2001;357(9274):2075-9. [pmid: 11445099].
314 Poehl M, Holagschwandtner M, Bichler K, et al. IVF-patients with nonmale factor “to ICSI” or “not to ICSI” that is the question?. J Assist Reprod Genet. 2001;18(4):205-8. [pmid: 11432111].
315 Foong SC, Fleetham JA, O'Keane JA, et al. A prospective randomized trial of conventional in vitro fertilization versus intracytoplasmic sperm injection in unexplained infertility. J Assist Reprod Genet. 2006;23(3):137-40. [pmid: 16622804].
316 Kattera S, Chen C. Short coincubation of gametes in in vitro fertilization improves implantation and pregnancy rates: a prospective, randomized, controlled study. Fertil Steril. 2003;80(4):1017-21. [pmid: 14556826].
317 Morgia F, Torti M, Montigiani M, et al. Use of a medium buffered with N-hydroxyethylpiperazine-N-ethanesulfonate (HEPES) in intracytoplasmic sperm injection procedures is detrimental to the outcome of in vitro fertilization. Fertil Steril. 2006;85(5):1415-9. [pmid: 16600227].
318 Wang WH, Meng L, Hackett RJ, et al. Rigorous thermal control during intracytoplasmic sperm injection stabilizes the meiotic spindle and improves fertilization and pregnancy rates. Fertil Steril. 2002;77(6):1274-7. [pmid: 12057740].
319 Verhulst SM, Cohlen BJ, Hughes E, et al. Intra-uterine insemination for unexplained subfertility [Full Review]. Cochrane Database of Systematic Reviews 2006, Issue 4. Art. No.: CD001838. DOI: 10.1002/14651858.CD001838.pub3.
320 van Rumste MME, Evers JLH, Farquhar CM. Intra-cytoplasmic sperm injection versus conventional techniques for oocyte insemination during in vitro fertilisation in patients with non-male subfertility [Full Review]. Cochrane Database of Systematic Reviews 2003, Issue 2. Art. No.: CD001301. DOI: 10.1002/14651858.CD001301.
321 Quinn P, Cooke S. Equivalency of culture media for human in vitro fertilization formulated to have the same pH under an atmosphere containing 5% or 6% carbon dioxide. Fertil Steril. 2004;81(6):1502-6. [pmid: 15193468].
322 Ben-Yosef D, Amit A, Azem F, et al. Prospective randomized comparison of two embryo culture systems: P1 medium by Irvine Scientific and the Cook IVF Medium. J Assist Reprod Genet. 2004;21(8):291-5. [pmid: 15568329].
323 Balaban B, Yakin K, Isiklar A, et al. Utilization of high-security straws for embryo freezing in an in vitro fertilization program: a prospective, randomized study. Fertil Steril. 2007;87(3):691-6. [pmid: 17173906].
324 Chen C, Kattera S. Comparison of pronuclear zygote morphology and early cleavage status of zygotes as additional criteria in the selection of day 3 embryos: a randomized study. Fertil Steril. 2006;85(2):347-52. [pmid: 16595210].
325 Emiliani S, Fasano G, Vandamme B, et al. Impact of the assessment of early cleavage in a single embryo transfer policy. Reproductive Biomedicine Online. 2006;13(2):255-60. [pmid: 16895641].
326 Staessen C, Platteau P, Van Assche E, et al. Comparison of blastocyst transfer with or without preimplantation genetic diagnosis for aneuploidy screening in couples with advanced maternal age: a prospective randomized controlled trial. Hum Reprod. 2004;19(12):2849-58. [pmid: 15471934].
327 Mastenbroek S, Twisk M, van Echten-Arends J, et al. In vitro fertilization with preimplantation genetic screening. N Engl J Med. 2007;357(1):9-17. [pmid: 17611204].
328 Twisk M, Mastenbroek S, van Wely M, et al. Preimplantation genetic screening for abnormal number of chromosomes (aneuploidies) in in vitro fertilisation or intracytoplasmic sperm injection [Full Review]. Cochrane Database of Systematic Reviews 2006, Issue 1. Art. No.: CD005291. DOI: 10.1002/14651858.CD005291.pub2.
329 Sallam HN. Assisted hatching. Minerva Ginecol. 2004;56(3):223-34. [pmid: 15258534].
330 Jelinkova L, Pavelkova J, Strehler E, et al. Improved implantation rate after chemical removal of the zona pellucida. Fertil Steril. 2003;79(6):1299-303. [pmid: 12798874].
331 Petersen CG, Mauri AL, Baruffi RL, et al. Implantation failures: success of assisted hatching with quarter-laser zona thinning. Reproductive Biomedicine Online. 2005;10(2):224-9. [pmid: 15823228].
332 Rufas-Sapir O, Stein A, Orvieto R, et al. Is assisted hatching beneficial in patients with recurrent implantation failures?. Clin Exp Obstet Gynecol. 2004;31(2):110-2. [pmid: 15266762].
333 Nagy ZP, Taylor T, Elliott T, et al. Removal of lysed blastomeres from frozen-thawed embryos improves implantation and pregnancy rates in frozen embryo transfer cycles. Fertil Steril. 2005;84(6):1606-12. [pmid: 16359953].
334 Primi MP, Senn A, Montag M, et al. A European multicentre prospective randomized study to assess the use of assisted hatching with a diode laser and the benefit of an immunosuppressive/antibiotic treatment in different patient populations. Hum Reprod. 2004;19(10):2325-33. [pmid: 15284215].
335 Sifer C, Sellami A, Poncelet C, et al. A prospective randomized study to assess the benefit of partial zona pellucida digestion before frozen-thawed embryo transfers. Hum Reprod. 2006;21(9):2384-9. [pmid: 16772285].
336 Ng EH, Naveed F, Lau EY, et al. A randomized double-blind controlled study of the efficacy of laser-assisted hatching on implantation and pregnancy rates of frozen-thawed embryo transfer at the cleavage stage. Hum Reprod. 2005;20(4):979-85. [pmid: 15665025].
337 Petersen CG, Mauri AL, Baruffi RL, et al. Zona thinning with a noncontact diode laser in ICSI embryos from women of advanced age. J Assist Reprod Genet. 2002;19(11):512-6. [pmid: 12484493].
338 Frydman N, Madoux S, Hesters L, et al. A randomized double-blind controlled study on the efficacy of laser zona pellucida thinning on live birth rates in cases of advanced female age. Hum Reprod. 2006;21(8):2131-5. [pmid: 16644913].
339 Makrakis E, Angeli I, Agapitou K, et al. Laser versus mechanical assisted hatching: a prospective study of clinical outcomes. Fertil Steril. 2006;86(6):1596-600. [pmid: 17055494].
340 Nadir Ciray H, Bener F, Karagenc L, et al. Impact of assisted hatching on ART outcome in women with endometriosis. Hum Reprod. 2005;20(9):2546-9. [pmid: 15905297].
341 Sagoskin AW, Levy MJ, Tucker MJ, et al. Laser assisted hatching in good prognosis patients undergoing in vitro fertilization-embryo transfer: a randomized controlled trial. Fertil Steril. 2007;87(2):283-7. [pmid: 17094975].
342 Baruffi RL, Mauri AL, Petersen CG, et al. Zona thinning with noncontact diode laser in patients aged < or = 37 years with no previous failure of implantation: a prospective randomized study. J Assist Reprod Genet. 2000;17(10):557-60. [pmid: 11212860].
343 Isik AZ, Vicdan K, Kaba A, et al. Comparison of zona manipulated and zona intact blastocyst transfers: a prospective randomized trial. J Assist Reprod Genet. 2000;17(3):135-9. [pmid: 10911572].
344 Ma S, Rowe T, Yuen BH. Impact of assisted hatching on the outcome of intracytoplasmic sperm injection: a prospective, randomized clinical trial and pregnancy follow-up. Fertil Steril. 2006;85(4):895-900. [pmid: 16580371].
345 Seif MMW, Edi-Osagie ECO, Farquhar C, et al. Assisted hatching on assisted conception (IVF & ICSI) [Full Review]. Cochrane Database of Systematic Reviews 2006, Issue 1. Art. No.: CD001894. DOI: 10.1002/14651858.CD001894.pub3.
346 Oatway C, Gunby J, Daya S. Day three versus day two embryo transfer following in vitro fertilization or intracytoplasmic sperm injection [Full Review]. Cochrane Database of Systematic Reviews 2004, Issue 2. Art. No.: CD004378. DOI: 10.1002/14651858.CD004378.pub2.
347 Blake DA, Farquhar CM, Johnson N, et al. Cleavage stage versus blastocyst stage embryo transfer in assisted conception [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 4. Art. No.: CD002118. DOI: 10.1002/14651858.CD002118.pub3.
348 Dale B, Fiorentino A, de Simone ML, et al. Zygote versus embryo transfer: a prospective randomized multicenter trial. J Assist Reprod Genet. 2002;19(10):456-61. [pmid: 12416649].
349 Jaroudi K, Al-Hassan S, Sieck U, et al. Zygote transfer on day 1 versus cleavage stage embryo transfer on day 3: a prospective randomized trial. Hum Reprod. 2004;19(3):645-8. [pmid: 14998964].
350 Laverge H, De Sutter P, Van der Elst J, et al. A prospective, randomized study comparing day 2 and day 3 embryo transfer in human IVF. Hum Reprod. 2001;16(3):476-80. [pmid: 11228214].
351 Pantos K, Makrakis E, Stavrou D, et al. Comparison of embryo transfer on day 2, day 3, and day 6: a prospective randomized study. Fertil Steril. 2004;81(2):454-5. [pmid: 14967390].
352 Baruffi RL, Mauri AL, Petersen C, et al. Day 2 vs. day 3 embryo transfer after intracytoplasmic sperm injection. A prospective, randomized study. J Reprod Med. 2003;48(8):631-4. [pmid: 12971145].
353 Bahceci M, Ulug U, Ciray HN, et al. Efficiency of changing the embryo transfer time from day 3 to day 2 among women with poor ovarian response: a prospective randomized trial. Fertil Steril. 2006;86(1):81-5. [pmid: 16716322].
354 Kolibianakis EM, Zikopoulos K, Verpoest W, et al. Should we advise patients undergoing IVF to start a cycle leading to a day 3 or a day 5 transfer?. Hum Reprod. 2004;19(11):2550-4. [pmid: 15298978].
355 Papanikolaou EG, Camus M, Kolibianakis EM, et al. In vitro fertilization with single blastocyst-stage versus single cleavage-stage embryos. N Engl J Med. 2006;354(11):1139-46. [pmid: 16540614].
356 Karaki RZ, Samarraie SS, Younis NA, et al. Blastocyst culture and transfer: a step toward improved in vitro fertilization outcome. Fertil Steril. 2002;77(1):114-8. [pmid: 11779600].
357 Levitas E, Lunenfeld E, Har-Vardi I, et al. Blastocyst-stage embryo transfer in patients who failed to conceive in three or more day 2–3 embryo transfer cycles: a prospective, randomized study. Fertil Steril. 2004;81(3):567-71. [pmid: 15037404].
358 Papanikolaou EG, D'haeseleer E, Verheyen G, et al. Live birth rate is significantly higher after blastocyst transfer than after cleavage-stage embryo transfer when at least four embryos are available on day 3 of embryo culture. A randomized prospective study. Hum Reprod. 2005;20(11):3198-203. [pmid: 16055454].
359 Hreinsson J, Rosenlund B, Fridstrom M, et al. Embryo transfer is equally effective at cleavage stage and blastocyst stage: a randomized prospective study. Eur J Obstet Gynecol Reprod Biol. 2004;117(2):194-200. [pmid: 15541857].
360 Hsieh YY, Tsai HD, Chang FC. Routine blastocyst culture and transfer: 201 patients' experience. J Assist Reprod Genet. 2000;17(8):405-8. [pmid: 11062848].
361 Bungum M, Bungum L, Humaidan P, et al. Day 3 versus day 5 embryo transfer: a prospective randomized study. Reproductive Biomedicine Online. 2003;7(1):98-104. [pmid: 12930586].
362 Montag M, van der Ven K, Dorn C, et al. Extended embryo culture reduces the implantation rate on day 4 and day 5 when only a maximum of three embryos are cultured beyond the pronuclear stage. Eur J Obstet Gynecol Reprod Biol. 2006;124(1):65-9. [pmid: 16188376].
363 Gardner DK, Surrey E, Minjarez D, et al. Single blastocyst transfer: a prospective randomized trial. Fertil Steril. 2004;81(3):551-5. [pmid: 15037401].
364 Heijnen EM, Eijkemans MJ, De Klerk C, et al. A mild treatment strategy for in-vitro fertilisation: a randomised non-inferiority trial. Lancet. 2007;369(9563):743-9. [pmid: 17336650].
365 Thurin A, Hausken J, Hillensjo T, et al. Elective single-embryo transfer versus double-embryo transfer in in vitro fertilization. N Engl J Med. 2004;351(23):2392-402. [pmid: 15575055].
366 van Montfoort AP, Fiddelers AA, Janssen JM, et al. In unselected patients, elective single embryo transfer prevents all multiples, but results in significantly lower pregnancy rates compared with double embryo transfer: a randomized controlled trial. Hum Reprod. 2006;21(2):338-43. [pmid: 16253973].
367 Lukassen HG, Braat DD, Wetzels AM, et al. Two cycles with single embryo transfer versus one cycle with double embryo transfer: a randomized controlled trial. Hum Reprod. 2005;20(3):702-8. [pmid: 15618254].
368 Heijnen EM, Klinkert ER, Schmoutziguer AP, et al. Prevention of multiple pregnancies after IVF in women 38 and older: a randomized study. Reproductive Biomedicine Online. 2006;13(3):386-93. [pmid: 16984771].
369 Pandian Z, Templeton A, Serour G, et al. Number of embryos for transfer after IVF and ICSI: a Cochrane review. Hum Reprod. 2005;20(10):2681-7. [pmid: 16183994].
370 Reddy UM, Wapner RJ, Rebar RW, et al. Infertility, assisted reproductive technology, and adverse pregnancy outcomes: executive summary of a National Institute of Child Health and Human Development workshop. Obstet Gynecol. 2007;109(4):967-77. [pmid: 17400861].
371 Schieve LA, Rasmussen SA, Buck GM, et al. Are children born after assisted reproductive technology at increased risk for adverse health outcomes?. Obstet Gynecol. 2004;103(6):1154-63. [pmid: 15172847].
372 Helmerhorst FM, Perquin DA, Donker D, et al. Perinatal outcome of singletons and twins after assisted conception: a systematic review of controlled studies. BMJ. 2004;328(7434):261-6. [pmid: 14742347]. [pmcid: 324454].
373 Wilcox AJ, Weinberg CR, O'Connor JF, et al. Incidence of early loss of pregnancy. N Engl J Med. 1988;319(4):189-94. [pmid: 3393170].
374 Gray RH, Wu LY. Subfertility and risk of spontaneous abortion. Am J Public Health. 2000;90(9):1452-4. [pmid: 10983206]. [pmcid: 1447624].
375 Schieve LA, Tatham L, Peterson HB, et al. Spontaneous abortion among pregnancies conceived using assisted reproductive technology in the United States. Obstet Gynecol. 2003;101(5 Pt 1):959-67. [pmid: 12738158].
376 La Sala GB, Nucera G, Gallinelli A, et al. Spontaneous embryonic loss following in vitro fertilization: incidence and effect on outcomes. Am J Obstet Gynecol. 2004;191(3):741-6. [pmid: 15467533].
377 Spandorfer SD, Davis OK, Barmat LI, et al. Relationship between maternal age and aneuploidy in in vitro fertilization pregnancy loss. Fertil Steril. 2004;81(5):1265-9. [pmid: 15136087].
378 Tummers P, De Sutter P, Dhont M. Risk of spontaneous abortion in singleton and twin pregnancies after IVF/ICSI. Hum Reprod. 2003;18(8):1720-3. [pmid: 12871890].
379 Matias A, Oliveira C, da Silva JT, et al. The effect of ICSI, maternal age, and embryonic stage on early clinical loss rate of twin versus singleton pregnancies. Eur J Obstet Gynecol Reprod Biol. 2007;130(2):212-5. [pmid: 16806650].
380 Ulug U, Jozwiak EA, Mesut A, et al. Survival rates during the first trimester of multiple gestations achieved by ICSI: a report of 1448 consecutive multiples. Hum Reprod. 2004;19(2):360-4. [pmid: 14747181].
381 Farr SL, Schieve LA, Jamieson DJ. Pregnancy loss among pregnancies conceived through assisted reproductive technology, United States, 1999-2002. Am J Epidemiol. 2007;165(12):1380-8. [pmid: 17351291].
382 Winter E, Wang J, Davies MJ, et al. Early pregnancy loss following assisted reproductive technology treatment. Hum Reprod. 2002;17(12):3220-3. [pmid: 12456627].
383 Wang JX, Davies MJ, Norman RJ. Polycystic ovarian syndrome and the risk of spontaneous abortion following assisted reproductive technology treatment. Hum Reprod. 2001;16(12):2606-9. [pmid: 11726582].
384 La Sala GB, Nucera G, Gallinelli A, et al. Spontaneous embryonic loss after in vitro fertilization with and without intracytoplasmic sperm injection. Fertil Steril. 2004;82(6):1536-9. [pmid: 15589856].
385 Lathi RB, Milki AA. Rate of aneuploidy in miscarriages following in vitro fertilization and intracytoplasmic sperm injection. Fertil Steril. 2004;81(5):1270-2. [pmid: 15136088].
386 Seeber BE, Barnhart KT. Suspected ectopic pregnancy [erratum appears in Obstet Gynecol. 2006 Apr;107(4):955]. Obstet Gynecol. 2006;107(2 Pt 1):399-413. [pmid: 16449130].
387 Clayton HB, Schieve LA, Peterson HB, et al. Ectopic pregnancy risk with assisted reproductive technology procedures. Obstet Gynecol. 2006;107(3):595-604. [pmid: 16507930].
388 Fernandez H, Gervaise A. Ectopic pregnancies after infertility treatment: modern diagnosis and therapeutic strategy. Hum Reprod Update. 2004;10(6):503-13. [pmid: 15388673].
389 Check JH, Choe JK, Katsoff B, et al. Ectopic pregnancy is not more likely following fresh vs frozen embryo transfer. Clin Exp Obstet Gynecol. 2005;32(2):95-6. [pmid: 16108389].
390 Jun SH, Milki AA. Ectopic pregnancy rates with frozen compared with fresh blastocyst transfer. Fertil Steril. 2007;88(3):629-31. [pmid: 17434510].
391 Jun SH, Milki AA. Assisted hatching is associated with a higher ectopic pregnancy rate. Fertil Steril. 2004;81(6):1701-3. [pmid: 15193502].
392 American College of Obstetricians and Gynecologists. Screening for fetal chromosomal abnormalities. Practice Bulletin No. 77. American College of Obstetricians and Gynecologists: Washington, DC; January 2007.
393 Weisz B, Rodeck CH. An update on antenatal screening for Down's syndrome and specific implications for assisted reproduction pregnancies. Hum Reprod Update. 2006;12(5):513-8. [pmid: 16672245].
394 Maymon R, Shulman A. Serial first- and second-trimester Down's syndrome screening tests among IVF-versus naturally-conceived singletons. Hum Reprod. 2002;17(4):1081-5. [pmid: 11925409].
395 Hui PW, Tang MH, Lam YH, et al. Nuchal translucency in pregnancies conceived after assisted reproduction technology. Ultrasound Obstet Gynecol. 2005;25(3):234-8. [pmid: 15736183].
396 Maymon R, Shulman A. Integrated first- and second-trimester Down syndrome screening test among unaffected IVF pregnancies. Prenat Diagn. 2004;24(2):125-9. [pmid: 14974121].
397 Lambert-Messerlian G, Dugoff L, Vidaver J, et al. First- and second-trimester Down syndrome screening markers in pregnancies achieved through assisted reproductive technologies (ART): a FASTER trial study. Prenat Diagn. 2006;26(8):672-8. [pmid: 16764012].
398 Wojdemann KR, Larsen SO, Shalmi A, et al. First trimester screening for Down syndrome and assisted reproduction: no basis for concern. Prenat Diagn. 2001;21(7):563-5. [pmid: 11494292].
399 Orlandi F, Rossi C, Allegra A, et al. First trimester screening with free beta-hCG, PAPP-A and nuchal translucency in pregnancies conceived with assisted reproduction. Prenat Diagn. 2002;22(8):718-21. [pmid: 12210583].
400 Rice JD, McIntosh SF, Halstead AC. Second-trimester maternal serum screening for Down syndrome in in vitro fertilization pregnancies. Prenat Diagn. 2005;25(3):234-8. [pmid: 15791658].
401 Muller F, Dreux S, Lemeur A, et al. Medically assisted reproduction and second-trimester maternal serum marker screening for Down syndrome. Prenat Diagn. 2003;23(13):1073-6. [pmid: 14691995].
402 Tul N, Novak-Antolic Z. Serum PAPP-A levels at 10–14 weeks of gestation are altered in women after assisted conception. Prenat Diagn. 2006;26(13):1206-11. [pmid: 17075793].
403 Maymon R, Jauniaux E, Holmes A, et al. Nuchal translucency measurement and pregnancy outcome after assisted conception versus spontaneously conceived twins. Hum Reprod. 2001;16(9):1999-2004. [pmid: 11527912].
404 Hui PW, Tang MH, Ng EH, et al. Nuchal translucency in dichorionic twins conceived after assisted reproduction. Prenat Diagn. 2006;26(6):510-3. [pmid: 16639691].
405 Raty R, Virtanen A, Koskinen P, et al. Maternal midtrimester serum AFP and free beta-hCG levels in in vitro fertilization twin pregnancies. Prenat Diagn. 2000;20(3):221-3. [pmid: 10719325].
406 Koudstaal J, Braat DD, Bruinse HW, et al. Obstetric outcome of singleton pregnancies after IVF: a matched control study in four Dutch university hospitals. Hum Reprod. 2000;15(8):1819-25. [pmid: 10920110].
407 Perri T, Chen R, Yoeli R, et al. Are singleton assisted reproductive technology pregnancies at risk of prematurity?. J Assist Reprod Genet. 2001;18(5):245-9. [pmid: 11464574].
408 Poikkeus P, Unkila-Kallio L, Vilska S, et al. Impact of infertility characteristics and treatment modalities on singleton pregnancies after assisted reproduction. Reproductive Biomedicine Online. 2006;13(1):135-44. [pmid: 16820125].
409 Klemetti R, Gissler M, Hemminki E. Comparison of perinatal health of children born from IVF in Finland in the early and late 1990s. Hum Reprod. 2002;17(8):2192-8. [pmid: 12151458].
410 Wang JX, Norman RJ, Kristiansson P. The effect of various infertility treatments on the risk of preterm birth. Hum Reprod. 2002;17(4):945-9. [pmid: 11925387].
411 De Neubourg D, Gerris J, Mangelschots K, et al. The obstetrical and neonatal outcome of babies born after single-embryo transfer in IVF/ICSI compares favourably to spontaneously conceived babies. Hum Reprod. 2006;21(4):1041-6. [pmid: 16428333].
412 De Sutter P, Delbaere I, Gerris J, et al. Birthweight of singletons after assisted reproduction is higher after single- than after double-embryo transfer. Hum Reprod. 2006;21(10):2633-7. [pmid: 16785258].
413 Poikkeus P, Gissler M, Unkila-Kallio L, et al. Obstetric and neonatal outcome after single embryo transfer. Hum Reprod. 2007;22(4):1073-9. [pmid: 17251357].
414 Rajesh H, Yap HA, Wu YJ. Pregnancy outcomes from in-vitro fertilisation and intracytoplasmic sperm injection: a comparison. Singapore Med J. 2006;47(4):309-14. [pmid: 16572243].
415 Bonduelle M, Liebaers I, Deketelaere V, et al. Neonatal data on a cohort of 2889 infants born after ICSI (1991-1999) and of 2995 infants born after IVF (1983-1999). Hum Reprod. 2002;17(3):671-94. [pmid: 11870121].
416 Ombelet W, Martens G, De Sutter P, et al. Perinatal outcome of 12,021 singleton and 3108 twin births after non-IVF-assisted reproduction: a cohort study. Hum Reprod. 2006;21(4):1025-32. [pmid: 16339165].
417 McGovern PG, Llorens AJ, Skurnick JH, et al. Increased risk of preterm birth in singleton pregnancies resulting from in vitro fertilization-embryo transfer or gamete intrafallopian transfer: a meta-analysis. Fertil Steril. 2004;82(6):1514-20. [pmid: 15589852].
418 Jackson RA, Gibson KA, Wu YW, et al. Perinatal outcomes in singletons following in vitro fertilization: a meta-analysis. Obstet Gynecol. 2004;103(3):551-63. [pmid: 14990421].
419 McDonald SD, Murphy K, Beyene J, et al. Perinatel outcomes of singleton pregnancies achieved by in vitro fertilization: a systematic review and meta-analysis. J Obstet Gynaecol Can. 2005;27(5):449-59. [pmid: 16100639].
420 Thornton JG. Progesterone and preterm labor—still no definite answers. N Engl J Med. 2007;357(5):499-501. [pmid: 17671259].
421 Elliott JP. High-order multiple gestations. Semin Perinatol. 2005;29(5):305-11. [pmid: 16360489].
422 Cheang CU, Huang LS, Lee TH, et al. A comparison of the outcomes between twin and reduced twin pregnancies produced through assisted reproduction. Fertil Steril. 2007;88(1):47-52. [pmid: 17270181].
423 Choi SJ, Kim HS, Roh CR. Pregnancy outcomes of twins after in vitro and spontaneous fertilization. Int J Gynaecol Obstet. 2006;94(1):49-51. [pmid: 16730009].
424 Huang CT, Au HK, Chien LW, et al. Twin pregnancy outcome among cases of spontaneous conception, intrauterine insemination, and in vitro fertilization/intracytoplasmic sperm injection. Fertil Steril. 2006;86(4):1017-9. [pmid: 16963039].
425 Putterman S, Figueroa R, Garry D, et al. Comparison of obstetric outcomes in twin pregnancies after in vitro fertilization, ovarian stimulation and spontaneous conception. Journal of Maternal-Fetal & Neonatal Medicine. 2003;14(4):237-40. [pmid: 14738169].
426 Koudstaal J, Bruinse HW, Helmerhorst FM, et al. Obstetric outcome of twin pregnancies after in-vitro fertilization: a matched control study in four Dutch university hospitals. Hum Reprod. 2000;15(4):935-40. [pmid: 10739845].
427 Manoura A, Korakaki E, Hatzidaki E, et al. Perinatal outcome of twin pregnancies after in vitro fertilization. Acta Obstet Gynecol Scand. 2004;83(11):1079-84. [pmid: 15488126].
428 Nassar AH, Usta IM, Rechdan JB, et al. Pregnancy outcome in spontaneous twins versus twins who were conceived through in vitro fertilization. Am J Obstet Gynecol. 2003;189(2):513-8. [pmid: 14520227].
429 Pinborg A, Loft A, Rasmussen S, et al. Neonatal outcome in a Danish national cohort of 3438 IVF/ICSI and 10,362 non-IVF/ICSI twins born between 1995 and 2000. Hum Reprod. 2004;19(2):435-41. [pmid: 14747193].
430 Pinborg A, Loft A, Schmidt L, et al. Maternal risks and perinatal outcome in a Danish national cohort of 1005 twin pregnancies: the role of in vitro fertilization. Acta Obstet Gynecol Scand. 2004;83(1):75-84. [pmid: 14678089].
431 Saygan-Karamursel B, Tekam O, Aksu T, et al. Perinatal outcomes of spontaneous twins compared with twins conceived through intracytoplasmic sperm injection. J Perinat Med. 2006;34(2):132-8. [pmid: 16519618].
432 Verstraelen H, Goetgeluk S, Derom C, et al. Preterm birth in twins after subfertility treatment: population based cohort study. BMJ. 2005;331(7526):1173. [pmid: 16249191]. [pmcid: 1285094].
433 Zuppa AA, Maragliano G, Scapillati ME, et al. Neonatal outcome of spontaneous and assisted twin pregnancies. Eur J Obstet Gynecol Reprod Biol. 2001;95(1):68-72. [pmid: 11267723].
434 Isaksson R, Gissler M, Tiitinen A. Obstetric outcome among women with unexplained infertility after IVF: a matched case-control study. Hum Reprod. 2002;17(7):1755-61. [pmid: 12093835].
435 Hvidtjorn D, Grove J, Schendel DE, et al. Cerebral palsy among children born after in vitro fertilization: the role of preterm delivery—a population-based, cohort study. Pediatrics. 2006;118(2):475-82. [pmid: 16882798].
436 Schieve LA, Meikle SF, Ferre C, et al. Low and very low birth weight in infants conceived with use of assisted reproductive technology. N Engl J Med. 2002;346(10):731-7. [pmid: 11882728].
437 Zhu JL, Obel C, Hammer Bech B, et al. Infertility, infertility treatment, and fetal growth restriction. Obstet Gynecol. 2007;110(6):1326-34. [pmid: 18055728]. [pmcid: 2365892].
438 Pinborg A, Lidegaard O, Freiesleben NC, et al. Vanishing twins: a predictor of small-for-gestational age in IVF singletons. Hum Reprod. 2007;22(10):2707-14. [pmid: 17728356].
439 Adler-Levy Y, Lunenfeld E, Levy A. Obstetric outcome of twin pregnancies conceived by in vitro fertilization and ovulation induction compared with those conceived spontaneously. Eur J Obstet Gynecol Reprod Biol. 2007;133(2):173-8. [pmid: 17056174].
440 Griebel CP, Halvorsen J, Golemon TB, et al. Management of spontaneous abortion. Am Fam Physician. 2005;72(7):1243-50. [pmid: 16225027].
441 Wilcox AJ, Baird DD, Weinberg CR. Time of implantation of the conceptus and loss of pregnancy. N Engl J Med. 1999;340(23):1796-9. [pmid: 10362823].
442 Ola B, Li TC. Implantation failure following in-vitro fertilization. Curr Opin Obstet Gynecol. 2006;18(4):440-5. [pmid: 16794426].
443 Edwards RG. Human implantation: the last barrier in assisted reproduction technologies?. Reproductive Biomedicine Online. 2006;13(6):887-904. [pmid: 17169215].
444 Vitiello D, Patrizio P. Implantation and early embryonic development: implications for pregnancy. Semin Perinatol. 2007;31(4):204-7. [pmid: 17825673].
445 Cross JC. Placental function in development and disease. Reproduction, Fertility, & Development. 2006;18(12):71-6.
446 American College of Obstetricians and Gynecologists. Diagnosis and management of preeclampsia. Practice Bulletin No. 33. American College of Obstetricians and Gynecologists: Washington, DC; January 2002.
447 Dokras A, Baredziak L, Blaine J, et al. Obstetric outcomes after in vitro fertilization in obese and morbidly obese women. Obstet Gynecol. 2006;108(1):61-9. [pmid: 16816057].
448 Lynch A, McDuffie R Jr, Murphy J, et al. Preeclampsia in multiple gestation: the role of assisted reproductive technologies. Obstet Gynecol. 2002;99(3):445-51. [pmid: 11864672].
449 Shevell T, Malone FD, Vidaver J, et al. Assisted reproductive technology and pregnancy outcome. Obstet Gynecol. 2005;106(5 Pt 1):1039-45. [pmid: 16260523].
450 Erez O, Vardi IS, Hallak M, et al. Preeclampsia in twin gestations: association with IVF treatments, parity and maternal age. Journal of Maternal-Fetal & Neonatal Medicine. 2006;19(3):141-6. [pmid: 16690506].
451 Ochsenkuhn R, Strowitzki T, Gurtner M, et al. Pregnancy complications, obstetric risks, and neonatal outcome in singleton and twin pregnancies after GIFT and IVF. Arch Gynecol Obstet. 2003;268(4):256-61. [pmid: 12904987].
452 Tabs D, Vejnovic T, Radunovic N. Preeclampsia and eclampsia in parturients from the in vitro fertilization program. Med Pregl. 2004;57(12):7-12. [pmid: 15327182].
453 Kozinszky Z, Zadori J, Orvos H, et al. Risk of cesarean section in singleton pregnancies after assisted reproductive techniques. J Reprod Med. 2003;48(3):160-4. [pmid: 12698772].
454 Hernandez-Diaz S, Werler MM, Mitchell AA. Gestational hypertension in pregnancies supported by infertility treatments: role of infertility, treatments, and multiple gestations. Fertil Steril. 2007;88(2):438-45. [pmid: 17449034].
455 Vollenhoven B, Clark S, Kovacs G, et al. Prevalence of gestational diabetes mellitus in polycystic ovarian syndrome (PCOS) patients pregnant after ovulation induction with gonadotrophins. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2000;40(1):54-8. [pmid: 10870780].
456 Romundstad LB, Romundstad PR, Sunde A, et al. Increased risk of placenta previa in pregnancies following IVF/ICSI; a comparison of ART and non-ART pregnancies in the same mother. Hum Reprod. 2006;21(9):2353-8. [pmid: 16728419].
457 Hjelmstedt A, Widstrom AM, Wramsby H, et al. Personality factors and emotional responses to pregnancy among IVF couples in early pregnancy: a comparative study. Acta Obstet Gynecol Scand. 2003;82(2):152-61. [pmid: 12648178].
458 Sydsjo G, Wadsby M, Kjellberg S, et al. Relationships and parenthood in couples after assisted reproduction and in spontaneous primiparous couples: a prospective long-term follow-up study. Hum Reprod. 2002;17(12):3242-50. [pmid: 12456631].
459 Poikkeus P, Saisto T, Unkila-Kallio L, et al. Fear of childbirth and pregnancy-related anxiety in women conceiving with assisted reproduction. Obstet Gynecol. 2006;108(1):70-6. [pmid: 16816058].
460 Kallen B, Finnstrom O, Nygren KG, et al. In vitro fertilization (IVF) in Sweden: risk for congenital malformations after different IVF methods. Birth Defects Research. 2005;73(3):162-9. [pmid: 15678490].
461 Anthony S, Buitendijk SE, Dorrepaal CA, et al. Congenital malformations in 4224 children conceived after IVF. Hum Reprod. 2002;17(8):2089-95. [pmid: 12151442].
462 Belva F, Henriet S, Liebaers I, et al. Medical outcome of 8-year-old singleton ICSI children (born >or=32 weeks' gestation) and a spontaneously conceived comparison group. Hum Reprod. 2007;22(2):506-15. [pmid: 16982659].
463 Bonduelle M, Bergh C, Niklasson A, et al. Medical follow-up study of 5-year-old ICSI children. Reproductive Biomedicine Online. 2004;9(1):91-101. [pmid: 15257828].
464 Bonduelle M, Wennerholm UB, Loft A, et al. A multi-centre cohort study of the physical health of 5-year-old children conceived after intracytoplasmic sperm injection, in vitro fertilization and natural conception. Hum Reprod. 2005;20(2):413-9. [pmid: 15576393].
465 Zhu JL, Basso O, Obel C, et al. Infertility, infertility treatment, and congenital malformations: Danish national birth cohort. BMJ. 2006;333(7570):679. [pmid: 16893903]. [pmcid: 1584372].
466 Zadori J, Kozinszky Z, Orvos H, et al. The incidence of major birth defects following in vitro fertilization. J Assist Reprod Genet. 2003;20(3):131-2. [pmid: 12735389].
467 El Hage S, Ghanem I, Safi CA, et al. The risk of neuro-orthopaedic malformations following in-vitro fertilization. Journal of Pediatric Orthopaedics, Part B. 2006;15(3):229-32.
468 Hansen M, Kurinczuk JJ, Bower C, et al. The risk of major birth defects after intracytoplasmic sperm injection and in vitro fertilization. N Engl J Med. 2002;346(10):725-30. [pmid: 11882727].
469 Katalinic A, Rosch C, Ludwig M, et al. Pregnancy course and outcome after intracytoplasmic sperm injection: a controlled, prospective cohort study. Fertil Steril. 2004;81(6):1604-16. [pmid: 15193484].
470 Klemetti R, Gissler M, Sevon T, et al. Children born after assisted fertilization have an increased rate of major congenital anomalies. Fertil Steril. 2005;84(5):1300-7. [pmid: 16275218].
471 Koivurova S, Hartikainen AL, Gissler M, et al. Neonatal outcome and congenital malformations in children born after in-vitro fertilization. Hum Reprod. 2002;17(5):1391-8. [pmid: 11980770].
472 Ludwig M, Katalinic A. Malformation rate in fetuses and children conceived after ICSI: results of a prospective cohort study. Reproductive Biomedicine Online. 2002;5(2):171-8. [pmid: 12419043].
473 Merlob P, Sapir O, Sulkes J, et al. The prevalence of major congenital malformations during two periods of time, 1986-1994 and 1995-2002 in newborns conceived by assisted reproduction technology. European Journal of Medical Genetics. 2005;48(1):5-11. [pmid: 15953400].
474 Olson CK, Keppler-Noreuil KM, Romitti PA, et al. In vitro fertilization is associated with an increase in major birth defects. Fertil Steril. 2005;84(5):1308-15. [pmid: 16275219].
475 Kuwata T, Matsubara S, Ohkuchi A, et al. The risk of birth defects in dichorionic twins conceived by assisted reproductive technology. Twin Research. 2004;7(3):223-7. [pmid: 15193165].
476 Buckett WM, Chian RC, Holzer H, et al. Obstetric outcomes and congenital abnormalities after in vitro maturation, in vitro fertilization, and intracytoplasmic sperm injection. Obstet Gynecol. 2007;110(4):885-91. [pmid: 17906024].
477 Wu YW, Croen LA, Henning L, et al. Potential association between infertility and spinal neural tube defects in offspring. Birth Defects Research. 2006;76(10):718-22. [pmid: 17022023].
478 Whiteman D, Murphy M, Hey K, et al. Reproductive factors, subfertility, and risk of neural tube defects: a case-control study based on the Oxford Record Linkage Study Register. Am J Epidemiol. 2000;152(9):823-8. [pmid: 11085393].
479 Kallen B, Robert-Gnansia E. Maternal drug use, fertility problems, and infant craniostenosis. Cleft Palate Craniofac J. 2005;42(6):589-93. [pmid: 16241169].
480 Reefhuis J, Honein MA, Shaw GM, et al. Fertility treatments and craniosynostosis: California, Georgia, and Iowa, 1993-1997. Pediatrics. 2003;111(5 Part 2):1163-6. [pmid: 12728131].
481 Aboulghar H, Aboulghar M, Mansour R, et al. A prospective controlled study of karyotyping for 430 consecutive babies conceived through intracytoplasmic sperm injection. Fertil Steril. 2001;76(2):249-53. [pmid: 11476768].
482 Lidegaard O, Pinborg A, Andersen AN. Imprinting diseases and IVF: Danish National IVF cohort study. Hum Reprod. 2005;20(4):950-4. [pmid: 15665017].
483 Rimm AA, Katayama AC, Diaz M, et al. A meta-analysis of controlled studies comparing major malformation rates in IVF and ICSI infants with naturally conceived children. J Assist Reprod Genet. 2004;21(12):437-43. [pmid: 15704519].
484 Ericson A, Nygren KG, Olausson PO, et al. Hospital care utilization of infants born after IVF. Hum Reprod. 2002;17(4):929-32. [pmid: 11925384].
485 Schimmel MS, Hammerman C, Lusky A, et al. Very low-birth-weight-infants conceived by in vitro fertilization are not at higher risk for mortality and morbidity: a population-based study. Fertil Steril. 2006;85(4):907-12. [pmid: 16580373].
486 McDonald S, Murphy K, Beyene J, et al. Perinatal outcomes of in vitro fertilization twins: a systematic review and meta-analyses. Am J Obstet Gynecol. 2005;193(1):141-52. [pmid: 16021072].
487 Pinborg A, Loft A, Rasmussen S, et al. Hospital care utilization of IVF/ICSI twins followed until 2–7 years of age: a controlled Danish national cohort study. Hum Reprod. 2004;19(11):2529-36. [pmid: 15319391].
488 Brinton LA, Kruger Kjaer S, Thomsen BL, et al. Childhood tumor risk after treatment with ovulation-stimulating drugs. Fertil Steril. 2004;81(4):1083-91. [pmid: 15066468].
489 Klip H, Burger CW, de Kraker J, et al. Risk of cancer in the offspring of women who underwent ovarian stimulation for IVF. Hum Reprod. 2001;16(11):2451-8. [pmid: 11679537].
490 Bruinsma F, Venn A, Lancaster P, et al. Incidence of cancer in children born after in-vitro fertilization. Hum Reprod. 2000;15(3):604-7. [pmid: 10686204].
491 Puumala SE, Ross JA, Olshan AF, et al. Reproductive history, infertility treatment, and the risk of acute leukemia in children with down syndrome: a report from the Children's Oncology Group. Cancer. 2007;110(9):2067-74. [pmid: 17849462].
492 Sun Y, Vestergaard M, Christensen J, et al. Epilepsy and febrile seizures in children of treated and untreated subfertile couples. Hum Reprod. 2007;22(1):215-20. [pmid: 16936302].
493 Stromberg B, Dahlquist G, Ericson A, et al. Neurological sequelae in children born after in-vitro fertilisation: a population-based study. Lancet. 2002;359(9305):461-5. [pmid: 11853790].
494 Hvidtjorn D, Grove J, Schendel D, et al. ‘Vanishing embryo syndrome’ in IVF/ICSI. Hum Reprod. 2005;20(9):2550-1. [pmid: 15890728].
495 Pinborg A, Loft A, Schmidt L, et al. Morbidity in a Danish national cohort of 472 IVF/ICSI twins, 1132 non-IVF/ICSI twins and 634 IVF/ICSI singletons: health-related and social implications for the children and their families. Hum Reprod. 2003;18(6):1234-43. [pmid: 12773452].
496 Sutcliffe AG, Taylor B, Saunders K, et al. Outcome in the second year of life after in-vitro fertilisation by intracytoplasmic sperm injection: a UK case-control study. Lancet. 2001;357(9274):2080-4. [pmid: 11445100].
497 Goody A, Rice F, Boivin J, et al. Twins born following fertility treatment: implications for quantitative genetic studies. Twin Research & Human Genetics: the Official Journal of the International Society for Twin Studies. 2005;8(4):337-45. [pmid: 16176718].
498 Place I, Englert Y. A prospective longitudinal study of the physical, psychomotor, and intellectual development of singleton children up to 5 years who were conceived by intracytoplasmic sperm injection compared with children conceived spontaneously and by in vitro fertilization. Fertil Steril. 2003;80(6):1388-97. [pmid: 14667874].
499 Agarwal P, Loh SK, Lim SB, et al. Two-year neurodevelopmental outcome in children conceived by intracytoplasmic sperm injection: prospective cohort study. BJOG. 2005;112(10):1376-83. [pmid: 16167940].
500 Maimburg RD, Vaeth M. Do children born after assisted conception have less risk of developing infantile autism?. Hum Reprod. 2007;22(7):1841-3. [pmid: 17456530].
501 Hardiman P, Pillay OC, Atiomo W. Polycystic ovary syndrome and endometrial carcinoma [erratum appears in Lancet. 2003 Sep 27;362(9389):1082]. Lancet. 2003;361(9371):1810-2. [pmid: 12781553].
502 Brinton L. Long-term effects of ovulation-stimulating drugs on cancer risk. Reproductive Biomedicine Online. 2007;15(1):38-44. [pmid: 17623533].
503 Ries LAG, Melbert D, Krapcho M, et al. SEER Cancer Statistics Review, 1975-2004, National Cancer Institute. Bethesda, MD, http://seer.cancer.gov/csr/1975_2004/, based on November 2006 SEER data submission, posted to the SEER web site, 2007.
504 Lerner-Geva L, Geva E, Lessing JB, et al. The possible association between in vitro fertilization treatments and cancer development. Int J Gynecol Cancer. 2003;13(1):23-7. [pmid: 12631215].
505 Brinton LA, Scoccia B, Moghissi KS, et al. Breast cancer risk associated with ovulation-stimulating drugs. Hum Reprod. 2004;19(9):2005-13. [pmid: 15217997].
506 Jensen A, Sharif H, Svare EI, et al. Risk of breast cancer after exposure to fertility drugs: results from a large Danish cohort study. Cancer Epidemiol Biomarkers Prev. 2007;16(7):1400-7. [pmid: 17585058].
507 Burkman RT, Tang MT, Malone KE, et al. Infertility drugs and the risk of breast cancer: findings from the National Institute of Child Health and Human Development Women's Contraceptive and Reproductive Experiences Study. Fertil Steril. 2003;79(4):844-51. [pmid: 12749419].
508 Terry KL, Willett WC, Rich-Edwards JW, et al. A prospective study of infertility due to ovulatory disorders, ovulation induction, and incidence of breast cancer. Arch Intern Med. 2006;166(22):2484-9. [pmid: 17159014].
509 Dor J, Lerner-Geva L, Rabinovici J, et al. Cancer incidence in a cohort of infertile women who underwent in vitro fertilization. Fertil Steril. 2002;77(2):324-7. [pmid: 11821091].
510 Kristiansson P, Bjor O, Wramsby H. Tumour incidence in Swedish women who gave birth following IVF treatment. Hum Reprod. 2007;22(2):421-6. [pmid: 17071821].
511 Venn A, Hemminki E, Watson L, et al. Mortality in a cohort of IVF patients. Hum Reprod. 2001;16(12):2691-6. [pmid: 11726597].
512 Gauthier E, Paoletti X, Clavel-Chapelon F, et al. Breast cancer risk associated with being treated for infertility: results from the French E3N cohort study. Hum Reprod. 2004;19(10):2216-21. [pmid: 15271872].
513 Lerner-Geva L, Keinan-Boker L, Blumstein T, et al. Infertility, ovulation induction treatments and the incidence of breast cancer—a historical prospective cohort of Israeli women. Breast Cancer Research & Treatment. 2006;100(2):201-12. [pmid: 16685587].
514 Brinton LA, Lamb EJ, Moghissi KS, et al. Ovarian cancer risk after the use of ovulation-stimulating drugs. Obstet Gynecol. 2004;103(6):1194-203. [pmid: 15172852].
515 Brinton LA, Lamb EJ, Moghissi KS, et al. Ovarian cancer risk associated with varying causes of infertility. Fertil Steril. 2004;82(2):405-14. [pmid: 15302291].
516 Parazzini F, Pelucchi C, Negri E, et al. Use of fertility drugs and risk of ovarian cancer. Hum Reprod. 2001;16(7):1372-5. [pmid: 11425815].
517 Rossing MA, Tang MT, Flagg EW, et al. A case-control study of ovarian cancer in relation to infertility and the use of ovulation-inducing drugs. Am J Epidemiol. 2004;160(11):1070-8. [pmid: 15561986].
518 Cusido M, Fabregas R, Pere BS, et al. Ovulation induction treatment and risk of borderline ovarian tumors. Gynecol Endocrinol. 2007;23(7):373-6. [pmid: 17701767].
519 Tworoger SS, Fairfield KM, Colditz GA, et al. Association of oral contraceptive use, other contraceptive methods, and infertility with ovarian cancer risk. Am J Epidemiol. 2007;166(8):894-901. [pmid: 17656616].
520 Ness RB, Cramer DW, Goodman MT, et al. Infertility, fertility drugs, and ovarian cancer: a pooled analysis of case-control studies. Am J Epidemiol. 2002;155(3):217-24. [pmid: 11821246].
521 Kashyap S, Moher D, Fung MF, et al. Assisted reproductive technology and the incidence of ovarian cancer: a meta-analysis. Obstet Gynecol. 2004;103(4):785-94. [pmid: 15051576].
522 Benshushan A, Paltiel O, Brzezinski A, et al. Ovulation induction and risk of endometrial cancer: a pilot study. Eur J Obstet Gynecol Reprod Biol. 2001;98(1):53-7. [pmid: 11516800].
523 Naucler P, Ryd W, Tornberg S, et al. Human papillomavirus and Papanicolaou tests to screen for cervical cancer. N Engl J Med. 2007;357(16):1589-97. [pmid: 17942872].
524 Cwikel J, Gidron Y, Sheiner E. Psychological interactions with infertility among women. Eur J Obstet Gynecol Reprod Biol. 2004;117(2):126-31. [pmid: 15541845].
525 Fisher JR, Hammarberg K, Baker HW. Assisted conception is a risk factor for postnatal mood disturbance and early parenting difficulties. Fertil Steril. 2005;84(2):426-30. [pmid: 16084885].
526 McMahon C, Gibson F. A special path to parenthood: parent-child relationships in families giving birth to singleton infants through IVF. Reproductive Biomedicine Online. 2002;5(2):179-86. [pmid: 12419044].
527 Repokari L, Punamaki RL, Poikkeus P, et al. Ante- and perinatal factors and child characteristics predicting parenting experience among formerly infertile couples during the child's first year: a controlled study. Journal of Family Psychology. 2006;20(4):670-9. [pmid: 17176203].
528 Repokari L, Punamaki RL, Unkila-Kallio L, et al. Infertility treatment and marital relationships: a 1-year prospective study among successfully treated ART couples and their controls. Hum Reprod. 2007;22(5):1481-91. [pmid: 17307807].
529 Ellison MA, Hotamisligil S, Lee H, et al. Psychosocial risks associated with multiple births resulting from assisted reproduction. Fertil Steril. 2005;83(5):1422-8. [pmid: 15866579].
530 Glazebrook C, Sheard C, Cox S, et al. Parenting stress in first-time mothers of twins and triplets conceived after in vitro fertilization. Fertil Steril. 2004;81(3):505-11. [pmid: 15037391].
531 Sheard C, Cox S, Oates M, et al. Impact of a multiple, IVF birth on post-partum mental health: a composite analysis. Hum Reprod. 2007;22(7):2058-65. [pmid: 17545565].
532 Tully LA, Moffitt TB, Caspi A. Maternal adjustment, parenting and child behaviour in families of school-aged twins conceived after IVF and ovulation induction. Journal of Child Psychology & Psychiatry & Allied Disciplines. 2003;44(3):316-25.
533 Yokoyama Y. Comparison of child-rearing problems between mothers with multiple children who conceived after infertility treatment and mothers with multiple children who conceived spontaneously. Twin Research. 2003;6(2):89-96. [pmid: 12723995].
534 Verhaak CM, Smeenk JM, Evers AW, et al. Women's emotional adjustment to IVF: a systematic review of 25 years of research. Hum Reprod Update. 2007;13(1):27-36. [pmid: 16940360].
535 Kjaergard LL, Villumsen J, Gluud C. Reported methodologic quality and discrepancies between large and small randomized trials in meta-analyses. Ann Intern Med. 2001;135(11):982-9. [pmid: 11730399].
536 Ioannidis JP, Cappelleri JC, Lau J. Issues in comparisons between meta-analyses and large trials. JAMA. 1998;279(14):1089-93. [pmid: 9546568].
537 LeLorier J, Gregoire G, Benhaddad A, et al. Discrepancies between meta-analyses and subsequent large randomized, controlled trials. N Engl J Med. 1997;337(8):536-42. [pmid: 9262498].
538 Daya S. Pitfalls in the design and analysis of efficacy trials in subfertility. Hum Reprod. 2003;18(5):1005-9. [pmid: 12721177].
539 Barlow DH. The design, publication and interpretation of research in Subfertility Medicine: uncomfortable issues and challenges to be faced. Hum Reprod. 2003;18(5):899-901. [pmid: 12721158].
540 European Society of Human Reproduction and Embryology. Three million babies born using assisted reproductive technologies. Press release. 2006. Available at: www.eshre.com/emc.asp?pageId=806. Accessed 30 January 2008.
541 Lykke JA, Langhoff-Roos J, Young B, et al. Population-based investigations to study the association of cardiovascular polymorphisms and adverse pregnancy outcome. Semin Perinatol. 2007;31(4):219-22. [pmid: 17825676].
542 Irgens HU, Reisaeter L, Irgens LM, et al. Long term mortality of mothers and fathers after pre-eclampsia: population based cohort study. BMJ. 2001;323(7323):1213-7. [pmid: 11719411]. [pmcid: 59993].
543 Ryan GL, Zhang SH, Dokras A, et al. The desire of infertile patients for multiple births. Fertil Steril. 2004;81(3):500-4. [pmid: 15037390].
544 Twisk M, van der Veen F, Repping S, et al. Preferences of subfertile women regarding elective single embryo transfer: additional in vitro fertilization cycles are acceptable, lower pregnancy rates are not. Fertil Steril. 2007;88(4):1006-9. [pmid: 17416363].
545 Scotland GS, McNamee P, Peddie VL, et al. Safety versus success in elective single embryo transfer: women's preferences for outcomes of in vitro fertilisation. BJOG. 2007;114(8):977-83. [pmid: 17578474].
546 Steures P, Berkhout JC, Hompes PG, et al. Patients' preferences in deciding between intrauterine insemination and expectant management. Hum Reprod. 2005;20(3):752-5. [pmid: 15640260].
547 Newton CR, McBride J, Feyles V, et al. Factors affecting patients' attitudes toward single- and multiple-embryo transfer. Fertil Steril. 2007;87(2):269-78. [pmid: 17097648].
548 Legro RS, Myers E. Surrogate end-points or primary outcomes in clinical trials in women with polycystic ovary syndrome?. Hum Reprod. 2004;19(8):1697-704. [pmid: 15192061].
549 Bayram N, van Wely M, van der Veen F, et al. Treatment preferences and trade-offs for ovulation induction in clomiphene citrate-resistant patients with polycystic ovary syndrome. Fertil Steril. 2005;84(2):420-5. [pmid: 16084884].
550 Dias S, McNamee R, Vail A. Evidence of improving quality of reporting of randomized controlled trials in subfertility. Hum Reprod. 2006;21(10):2617-27. [pmid: 16793995].
551 Behr B, Fisch JD, Racowsky C, et al. Blastocyst-ET and monozygotic twinning. J Assist Reprod Genet. 2000;17(6):349-51. [pmid: 11042833].