# Executive Summary

## Background

In the United States, approximately seven percent of married couples report at least 12 months of unprotected intercourse without conception, the most commonly used definition of infertility, while two percent of all women report an infertility-related clinic visit within the past year. Infertility causes significant emotional distress and its treatment costs well over $3 billion annually.

For many couples, treatment for infertility will ultimately include in vitro fertilization (IVF). The number of IVF cycles performed in the United States has increased from approximately 30,000 in 1996 to over 130,000 in 2005; during that time, the proportion of all U.S. births that resulted from IVF increased from 0.3 percent to almost 1 percent.

IVF and its variations are classified as “assisted reproductive technologies” (ART), which generally include any procedure that involves handling of both sperm and eggs outside of the body. This report covers not only ART, but two other types of infertility treatment - ovulation induction in women who do not ovulate frequently enough to conceive, most commonly as part of polycystic ovarian syndrome (PCOS); and superovulation, where women who do ovulate normally are given extra doses of hormones to stimulate the production of extra eggs.

Although all of these treatments improve the chances that a given couple will ultimately become parents, they also all carry the risk of multiple gestations. All multiple gestations, even twins, are at increased risk of preterm delivery, which carries increased risk of neonatal mortality, prolonged hospitalization, and long-term complications. This report reviews the evidence on the short- and long-term safety and effectiveness of interventions used for ovulation induction, superovulation, and ART.

## Methods

We searched MEDLINE^®^ for English-language studies published from January 2000 through January 2008. The search was supplemented by a hand search of reviews published by the Cochrane Menstrual Disorders and Subfertility Review Group. Primary research articles whose abstracts met inclusion criteria were subsequently reviewed by two independent reviewers; agreement by both reviewers was required for inclusion. For short-term outcomes (complications of treatment, pregnancy, live birth, multiples), we excluded non-randomized studies and studies where a pregnancy or live birth rate per subject could not be calculated. For long-term outcomes (pregnancy and long-term maternal complications, neonatal and childhood complications), we excluded studies with fewer than 100 subjects and those without a control group. Articles were abstracted for relevant details, and relative risks or odds ratios, with 95 percent confidence intervals, were calculated for the outcomes of interest for each study. Abstractions were read by a second reviewer as a check for accuracy. Quantitative synthesis with meta-analyses was outside of the scope of the review.

The review and evidence synthesis are structured around three key questions, involving (a) outcomes (including pregnancy, live birth, multiple gestation, and complications) after different interventions used in the treatment of anovulatory infertility and PCOS, and in superovulation; (b) the same outcomes after different interventions used in ART; and (c) longer-term outcomes for both the fetus/child (including spontaneous abortion, ectopic pregnancy, preterm delivery, low birth weight, neonatal and infant complications, and longer-term physical and developmental problems), and the mother (including pregnancy complications, cancer, and psychological/emotional problems).

## Results

We reviewed 5294 abstracts relevant to ART. For the three key questions discussed in this report, we reviewed 1210 full-text articles and included 478 articles. There were several consistent methodologic shortcomings, particularly with clinical studies. The number of randomized trials was small relative to the number of articles identified in the initial search. The majority of randomized trials that were included provided data only on pregnancy rates, not live birth or obstetric outcomes. Few studies were adequately powered to detect differences in pregnancy rates, let alone less frequent outcomes such as live birth, multiple gestations, or severe complications. Few studies of ART randomized couples to treatment for more than one cycle.

### Ovulation Induction

Clomiphene is an effective first-line therapy for women with PCOS. Metformin is, at best, no more effective, and, based on a large multi-center trial, less effective than clomiphene alone.

Although a statistically significant effect is not observed in individual studies, meta-analyses do demonstrate a significant increase in pregnancy rates in clomiphene-resistant women treated with metformin, a finding which should be confirmed in large studies. There is insufficient evidence to draw conclusions about the relative efficacy of aromatase inhibitors.

Use of laparoscopic cauterization of the ovaries, followed by ovulation induction if necessary, results in similar pregnancy and live birth rates, with significantly lower multiple gestation rates, compared to immediate gonadotropin use in clomiphene-resistant women; these rates may be further improved by the addition of metformin, although there are no data on possible long-term adverse outcomes of cautery.

### Superovulation in Ovulatory Women

Pooled data show significantly higher pregnancy rates with gonadotropins compared to clomiphene or aromatase inhibitors; there are trends toward higher rates of live birth, multiple pregnancy and hyperstimulation with gonadotropins, but study sizes are too small to draw definite conclusions regarding relative efficacies of these ovulation-inducing therapies.

There do not appear to be substantial differences in pregnancy rates between different gonadotropin preparations. Higher doses increase the risk of multiples and hyperstimulation without significant improvement in pregnancy rates. The addition of gonadotropin-releasing hormone (GnRH) antagonists to superovulation protocols may increase both pregnancy rates and twin gestation rates. Further studies adequately powered for the outcome of live birth per couple are needed.

### ART-the Female Partner

No clear superiority of any specific protocol for pituitary down-regulation with GnRH agonists was identified.

Although only one individual study comparing GnRH agonists to antagonists found a significant difference in pregnancy or live birth rates (in favor of agonists), published meta-analyses show significantly higher pregnancy and live birth rate with the use of agonists. Antagonists do result in significant decreases in gonadotropin requirements, and a significant decrease in the risk of ovarian hyperstimulation syndrome (OHSS).

Pooled results of individual trials of gonadotropin preparations suggest that human menopausal gonadotropins are superior in terms of pregnancy and live birth rates compared to recombinant follicle stimulating hormone (rFSH) in long protocol GnRH agonist regimens, with higher multiple pregnancy rates, and that the addition of recombinant luteinizing hormone (rLH) to rFSH improves live birth rates in poor responders. Based on differences in the amount of gonadotropin required, there may be economic advantages to some formulations.

Timing of human chorionic gonadotropin (hCG) administration for triggering oocyte maturation is important for optimizing live birth rates, but the optimal timing and threshold relative to follicular growth have not been determined. There does not appear to be any difference in pregnancy or live birth rates, or other major outcomes, between recombinant hCG and urinary hCG, although injection site reactions are more common with urinary hCG. In cycles using a GnRH antagonist for pituitary down-regulation, use of hCG is superior to use of a GnRH agonist.

There is insufficient evidence to determine the optimal method for endometrial preparation for frozen-thawed embryo transfer.

Ultrasound-guided embryo transfer consistently results in substantially improved (40 percent relative increase) pregnancy and live birth rates compared to various “clinical touch” methods. The consistency of this finding and the size of the effect are striking considering that the majority of interventions evaluated in this review do not show significant differences.

Some form of luteal support is necessary with ART, since both progesterone and hCG result in improved pregnancy rates compared to no treatment. Although there is no detectable difference between oral progesterone and the various formulations of vaginal progesterone, both result in lower pregnancy and live birth rates compared to intramuscular progesterone. The addition of estrogen to progesterone may improve outcomes, although additional larger studies are needed to confirm these findings.

The non-steroidal anti-inflammatory drug (NSAID) piroxicam significantly improved pregnancy and live birth rates in a general ART population, and further studies of NSAIDs are warranted. Randomized trials of intercessory prayer and acupuncture showed benefit, but there are remaining methodological questions (particularly the most appropriate control intervention) which need to be addressed.

### ART-the Embryo

ART results in much higher birth rates within 90 days than watchful waiting in eligible patients, although cumulative pregnancy rates were similar in one trial comparing ART to intrauterine insemination (IUI) and IUI after ovarian stimulation. There is no evidence of benefit for intracytoplasmic sperm injection (ICSI) compared to ART in patients with non-male factor infertility. Laboratory procedures used during fertilization, such as media and equipment used, may have significant impact on outcomes.

Assisted hatching improves pregnancy and live birth rates in couples with previous ART failure, but there is insufficient evidence to draw inferences about benefits in other groups.

Blastocyst transfer results in better live birth rates than day 3 transfer, especially in patients with a good prognosis. The disadvantage of delaying transfer is a reduction in the number of embryos available for transfer and for cryopreservation, and an increased risk of monozygotic twinning.

Although double embryo transfer results in higher pregnancy and live birth rates compared to single embryo transfer, multiple rates - almost all twins - are consistently higher. Strategies involving alternative methods for pituitary down-regulation, or involving multiple cycles with fewer embryo transfers per cycle, appear to result in similar live birth rates with fewer multiples.

### Long-Term Outcomes

Review of the literature on this topic included the inherent limitations of observational studies compared to randomized trials, difficulty in identifying appropriate controls, changes in clinical practice which may make findings about older treatments obsolete, and issues relating to generalizability of findings between countries.

Loss of the entire pregnancy is more common for singleton pregnancies than for twins after ART, suggesting that factors associated with successful implantation and placentation contribute to the likelihood of both multiple gestation and a successful pregnancy outcome.

False positive results for maternal testing for chromosomal abnormalities after assisted reproduction are more likely for second trimester serum screening, resulting in an increased false positive rate with combined screening strategies that incorporate both modalities.

Preterm delivery is approximately twice as likely in women pregnant with singleton pregnancies after infertility treatment compared to spontaneous singleton pregnancies. The evidence is most consistent for ART, but the risk was also increased in a large study of women pregnant after ovulation induction alone. The proportion of preterm deliveries that are indicated due to maternal/fetal complications versus those due to spontaneous preterm labor is unclear. Conversely, the risk of preterm birth in ART twins compared to spontaneous twins is either not elevated, or elevated to a lesser extent than in singletons, in the majority of studies.

Much of the elevated risk of low birth weight is due to the increased risk of preterm birth. However, studies that examined gestational age-specific weights found an increased risk of small-for-gestational age (SGA) infants among singleton, but not twin, pregnancies after infertility treatment.

Women pregnant after infertility treatment are at increased risk for disorders potentially related to abnormal implantation, including preeclampsia, placenta previa, and placental abruption. The extent to which specific treatments or underlying maternal/embryonic characteristics contribute to this risk is unclear.

Risks for major congenital anomalies are increased after infertility treatment, but much of this risk appears to be related to maternal and/or paternal characteristics, including a history of subfertility or infertility. Given the relative rarity of specific birth defects or syndromes, identifying an association between a specific exposure and subsequent risk is difficult.

In the neonatal period, although there is evidence of an increased risk for adverse outcomes, especially among singletons, it is unclear to what extent this is due to the observed increased preterm delivery rate. Large-scale studies that control for gestational age and birth weight are needed. In later infancy, there is a significantly increased hospitalization rate among children born after ART compared to the general population, but rates are similar when compared to children born to couples with a history of treated and untreated subfertility.

Children born after assisted reproduction have an increased risk of hospitalization and surgery compared to general population controls. There does not appear to be an increased risk of childhood cancers in children conceived after infertility treatments.

The available evidence suggests that there is not an increase in the risk of adverse neurodevelopmental outcomes in children born after infertility treatment that is not associated with the underlying condition of infertility or the well-established increased risk of prematurity and SGA. The available evidence on learning and other developmental outcomes is reassuring, but larger studies across a wider population are needed.

In general, infertility treatments involving ovarian stimulation do not appear to be associated with an increased risk of breast cancer, although non-significantly elevated risks were seen 20 years after exposure in one study, suggesting that continued monitoring is warranted.

Ovarian cancers are strongly associated with an infertility diagnosis; use of ovulation stimulating drugs does not appear to increase the risk above baseline levels in this patient population. As with breast cancer, increasing risk with increased duration with treatment cannot be ruled out with confidence.

Based on the available literature, there are no differences in psychological outcomes, including parenting skills, when comparing singleton pregnancies resulting from ART to spontaneous conceptions. If anything, mothers of infants resulting from ART have better outcomes, although there is some evidence that fathers may do worse on some scales. Multiple gestations significantly increase stress and depressive symptoms, especially for mothers of infants with chronic disabilities; to the extent that women undergoing ART are more likely to experience multiples, especially preterm multiples, they are more likely to experience these symptoms.

## Discussion

Limitations of this report include the restriction of studies to English language, the potential for missing relevant studies, and, perhaps, the lack of formal meta-analysis.

Future research considerations include attention to ameliorating some of the most common problems identified, including the use of multi-center trials to ensure adequate sample size; consensus on a minimally significant clinical difference to aid sample size estimates; development of standard data sets to facilitate meta-analysis, especially for less common outcomes; and study treatment durations that reflect clinical practice. Attention should also be paid to some of the political, regulatory, and financial barriers to high-quality research in infertility.

Research areas for prioritization for clinical research include almost all interventions currently in use, studies of effectiveness and long-term outcomes in male partners, and prevention of preterm birth. One area of great potential is further investigation of the potential link between infertility, infertility treatments, and pregnancy outcomes associated with implantation and placentation; these pregnancy outcomes are associated with long-term cardiovascular risk in the mother, suggesting yet another avenue for potential research. Finally, health services research into patient decisionmaking and methods for valuing the impact of infertility and its treatment on mother, father, and infant are crucial to helping design reasonable policy.