# Acknowledgments

The authors gratefully acknowledge R. Julian Irvine for assistance with project management, Rebecca Gray for editorial assistance, and Dr. Michael Handrigan, AHRQ Task Order Officer, for overall assistance.