# Future Research

## Study Design and Data Collection

Many, if not most, of the issues regarding study design discussed in this report have been consistently identified by other authors as barriers to drawing inferences about the safest and most effective interventions in reproductive medicine.^36,^,^538,539^ These include the use of surrogate endpoints, failure to report key endpoints such as live birth, analysis based on non-independent measures such as cycles or embryos rather than the patient or couple, inadequate sample size, failure to follow “standard-of-care” in treatment allocation, and the use of inappropriate statistical measures. Studies of longer term outcomes face a particular challenge in identifying the appropriate control group.

Potential ways that some of these deficiencies can be addressed include:

- More multi-center trials. Given the large sample sizes needed to demonstrate improvement in live birth rates, let alone differences in less common outcomes, it is highly unlikely that any one center could efficiently complete an adequately powered study for most questions. Any individual center with a high enough volume to recruit sufficient subjects in a reasonable time may well be too busy to have the necessary research infrastructure. Given the relative patient volume in academic compared to private centers, this may require identifying new ways to better incorporate large private centers into clinical trials, particularly non-industry trials.
- Consensus on a clinically meaningful minimal difference for all important outcomes. Study planning and peer review of grants and manuscripts would be much simpler if there were a consistent, generally accepted target. This threshold is somewhat arbitrary, and should include input from patients and the general public. Given that sample sizes of greater than 300 per arm are necessary to show a difference of 10 percent, given current IVF success rates, any difference smaller than 10 percent, even if judged important by patients or clinicians, is likely to require larger studies than are currently fundable.
- Development and use of standards for collecting data and/or reporting results to facilitate meta-analysis. For a variety of reasons, including academic pressure to publish, logistical issues in setting up and conducting multi-center trials, and the time required to conduct large scale trials,^539^ the smaller clinical trial conducted in an individual center is unlikely to be completely replaced by a mega-network for doing multicenter trials. In addition, even for large trials, sample size may be inadequate for less common outcomes, suggesting that there will be an ongoing need for meta-analysis. Development and use of a standard data set, using common definitions for outcomes and collection of data on key variables known to affect outcome, would facilitate these pooled analyses. Ideally, this would include options for long-term followup of both mother and baby.
- More trials using cumulative outcomes over several cycles. Ultimately, the probability that a couple will have a successful outcome over a full course of treatment, which may include multiple cycles, is more important than the individual cycle probability. Trials should, to the degree possible, reflect the clinical strategy. Depending on the estimated effect difference, a cumulative study might require fewer subjects, but more total overall cycles. There may well be trade-offs between the costs of several cycles in a subject versus the costs of recruitment.

## Barriers to High-Quality Research

We found that only approximately 20 percent of the included studies were performed in the United States. While this is roughly equivalent to the proportion of ART cycles performed in the United States compared to other countries,^540^ it is not necessarily consistent with a goal of U.S. scientific leadership. There are several factors which contribute to this disparity:

- Available data. Many European countries, in particular, have well-established national registries for a variety of outcomes that allow linkage, selection of appropriate controls, and large numbers. Although the U.S. ART registry is comprehensive, the main limitation is that there is no patient identifier, meaning that (a) the unit of analysis must be the cycle, rather than the patient, and (b) there is no way to link ART data to patient outcomes that might appear in other databases/registries, such as cancer or death registries.
- Incentives for evidence. As mentioned in the Introduction, the United States does not have either government or third-party payers generating pressure for evidence, compared to countries with single-payer or other systems that provide reimbursement for infertility services. This may be short-sighted: in a setting where a patient must pay for infertility but an insurance company pays for obstetric, neonatal, and, potentially, long-term health needs, the patient has every incentive to maximize the chances of pregnancy over the fewest cycles, since the greater long-term costs associated with multiple pregnancies are borne by outside payers (this discussion obviously considers only costs, not patient preferences for different outcomes). It is inherently difficult in most clinical settings to adequately counsel patients about balancing quantitative risks and benefits; this task is made even more difficult when the evidence base is inadequate. In addition, both practitioners and patients may not have sufficient familiarity with the methodological issues involved in interpreting outcome statistics to use this information to make truly informed decisions. For example, although the American Society for Reproductive Medicine (ASRM)/SART registry provides clinic-specific per-cycle data, these data are not adjusted for individual patient characteristics that may affect the likelihood of a successful outcome.
- Regulatory pressure for clinical trials. There is no FDA requirement for approval of new procedures, or variations on old procedures. Criteria for approval of medical devices rarely, if ever, include randomized trial data on efficacy of interventions using these devices. Only drugs used for specific indications require documentation of effectiveness in a randomized trial; not surprisingly, of the topics reviewed above, randomized trials were most common for newer pharmaceutical agents such as GnRH antagonists and recombinant hormones.
- Legislative barriers. The 1996 Dickey-Wicker Amendment to the 1996 Department of Health and Human Services appropriations bill states that no federal funds may be used for the following: “the creation of a human embryo or embryos for research purposes, or research in which a human embryo or embryos are destroyed, discarded, or knowingly subjected to risk of injury or death greater than that allowed for research on fetuses in utero.” “Human embryo” is defined broadly as “any organism, not protected as a human-subject under 45 C.F.R. 46 . . . that is derived by fertilization, parthenogenesis, cloning, or any other means from one or more human gametes or human diploid cells.” This standard is applied both to embryos intended for termination or discarding, and those intended to be carried to term. Since almost any clinical trial of assisted reproduction would carry some risk to some embryos, this has had the practical effect of inhibiting federally funded research. Recent controversies over the potential use of embryos for stem-cell research have added further pressures that inhibit research protocols.

Many of these barriers are the consequence of long-standing issues (e.g., paying for health care, abortion) that are unlikely to be resolved in the near future. However, a major step towards improving both the quality of data available for research and the immediate outcomes data available for patients would be mechanisms for ensuring that data in the ART registry are able to be analyzed at the individual patient level, and that validated risk adjustment methods are used for reporting clinic-specific results.

## Areas for Prioritizing Research

### I. Clinical Research

This review found that there is insufficient evidence to draw conclusions about the relative safety and efficacy of the majority of interventions used in ART.

First, high-quality, adequately powered studies of interventions currently in use should be the highest priority.

The few studies we identified regarding technical aspects of ART (for example, studies comparing the method for thermal regulation during ICSI^318^) suggested that, in some cases, the techniques and equipment used for individual aspects of the process can have a measurable impact on clinical outcomes. As new technologies are introduced, every effort should be made to test their clinical impact (or lack thereof) using appropriate study designs.

Studies of procedures performed on men, and on health outcomes in men after ART, even if no procedure is performed, should be a high priority. The few studies of psychological outcomes in men we did identify suggested that fathers may have more problems after ART compared to mothers.

Finally, as discussed in the section on preterm birth, the increased risk of preterm birth in ART singletons is equivalent to the increased risk observed in women with a history of prior preterm birth. Given this large relative and absolute risk, the effectiveness of progesterone for preventing preterm delivery in women with a history of preterm birth,^420^ and the evidence for the need for progesterone supplementation after ART, an appropriately designed and powered trial of continuing progesterone throughout pregnancy in singleton pregnancies after ART should be considered.

### II. Epidemiologic Research

Larger, longer term studies of outcomes in both mother and infant are needed. Ideally, these should be prospective, with adequate characterization of the exposure - in particular, identifying ways in which exposures differ from current practice to allow better estimation of the risk for current patients. Particular emphasis should be put on the long-term followup of participants in clinical trials.

One area we would highlight in particular is the association between infertility and infertility treatment, difficulty with implantation, and subsequent risk of adverse outcomes of pregnancy related to placentation. Insights derived from basic and translational research, particularly research that crosses disciplines, could prove invaluable both for infertility patients and obstetric patients. In addition, there is growing evidence of a link between adverse pregnancy outcomes and an increased risk of maternal cardiovascular morbidity and mortality in later life.^541,542^ If the link between infertility and adverse pregnancy outcomes is primarily due to the infertility rather than the treatment, then certain types of infertility besides PCOS (where the link is thought to be related to the accompanying insulin resistance) may also represent a risk factor for subsequent cardiovascular morbidity and mortality.

### III. Health Services Research

Finally, there are several promising avenues for health services research.

There are almost no data using utilities or other standard measures for patient preferences or decisionmaking in infertility. Studies finding that many couples consider a multiple gestation to be a favorable outcome, especially when compared to the prospect of either no pregnancy or prolonged treatment,^543^–^547^ suggest that further research into decisionmaking is needed. Such research would also help interpret the results of studies of the impact of insurance coverage changes, which to date show variable results.^30,31^ If cost-effectiveness analysis is ultimately going to be a tool for helping policymakers, then methods have to be developed that allow translation of outcomes of infertility treatment, which involve three (or more) individuals, into a common denominator such as quality-adjusted life years. The relative lack of a third-party intermediary between patient and clinician suggests that further studies of infertility practice as a market may provide insight into the potential impact of “market-based” reforms in other areas of health care.