# Discussion

This review has several limitations.

No literature search strategy has 100 percent sensitivity. We used standard electronic searching strategies, using appropriate key words, supplemented by hand searches of key articles and systematic reviews; we also asked peer reviewers of the draft report to suggest any relevant articles which may have been missed. At every stage of the review process, the presumption was towards inclusion if there was any doubt. However, it is entirely possible that some relevant articles may not have been identified in our search, and that the results of these articles would have changed our conclusions. In addition, studies may have been published subsequent to the cut-off date of our search (January 2008) that would affect our conclusions.

We limited our search to English-language articles. This may have led to omission of studies that would otherwise have met our inclusion criteria, especially for studies related to complementary and alternative medicine adjuncts, or observational studies of less common outcomes or different ethnic groups. Exclusion of abstracts may have led to the omission of important results, especially negative findings or more recent findings which have not yet appeared in press.

We did not include published abstracts. The primary effect of this exclusion is that very recently presented studies which have not yet been published but which may be relevant to this report have not been included.

We limited studies comparing the short-term results of different interventions to randomized trials. Although the randomized trial is considered the reference standard for evaluating treatment efficacy, it is possible that an observational study with sufficient sample size and enough detail on potential confounders to allow adequate statistical methods would have provided useful additional information. However, recent experience comparing the results of observational studies and randomized trials suggests that even when observational studies use state-of-the-art methodology, their results may not be confirmed by randomized trials. We also excluded studies that explicitly stated that they used a method of “quasi-randomization” (for example, allocating treatment based on alternate days of the week), since these study designs have been shown to be more likely to have biased results or exaggerated results,^36^ especially in the context of small trials.^535^

We limited studies comparing longer term outcomes to observational studies with at least 100 subjects and with a reasonable comparison group. Again, this may have led to the omission of potentially useful case series, or small case-control studies with particularly strong associations.

We did not perform meta-analyses for several reasons. First, based on the volume of literature to review and the rapid changes in clinical practice in this field, we limited our review to articles published in 2000 or later - comprehensive meta-analyses would have required more extensive searches. Second, both the Cochrane Menstrual Disorders and Subfertility Group, as well as independent researchers, have been quite active in producing formal meta-analyses, and, especially for more recent updates, there is no reason to believe we would have reached substantively different results. Third, given the diversity of patient populations and clinical protocols, there was substantial clinical heterogeneity among the included studies. In this setting, we believe a qualitative description of findings and methodological issues, along with specific recommendations for future research, is at least as helpful as a quantitative estimate of relative effect. Finally, the pooled results of multiple small trials do not always agree with the results of larger individual studies;^536,537^ the existence of a well-done meta-analysis does not necessarily obviate the need for an appropriately designed and sized trial, particularly if the goal is to establish equivalence.