# Results

## Ovulation Induction without Assisted Conception (Question 2)

### I. Research Question

Among women of reproductive age, what are the benefits and risks of Clomid^®^ and Pergonal^®^ (or other injectable super-ovulatory drugs) and Glucophage^®^, and how do they vary in different patient populations? Different patient populations include racial/ethnic groups and age by decade (or age groups comparable to those in the Centers for Disease Control and Prevention [CDC]-Society for Assisted Reproductive Technology [SART] national assisted reproductive technology [ART] success rates reports^14^). Risks include high rates of higher order multiples and ovarian hyperstimulation syndrome. Benefits include reduced time to achieve pregnancy, correction of ovulatory dysfunction, possible decreased miscarriage rates, and decreased gestational diabetes risk with Glucophage^®^.

### II. Approach

Agents that promote ovulation are used in two specific subgroups of infertile patients. First, the single most common etiology for infertility in the United States is anovulation or oligo-ovulation, most commonly as part of the polycystic ovarian syndrome (PCOS).^40^ Without ovulation, conception and pregnancy cannot occur; in these patients, use of techniques that stimulate ovulation is oriented towards correcting the primary etiology of infertility. We focused on treatment of anovulation solely in women seeking pregnancy: correction of endocrine abnormalities, including anovulation, in women not seeking pregnancy is clearly an important therapeutic goal, but the considerations in deciding on optimal therapy may be quite different.^41^ We did not include studies of women with anovulation due to hypothalamic amenorrhea or premature ovarian failure.

A second group of patients includes couples with unexplained infertility, mild male factor infertility, or other non-tubal etiologies. In theory, given patent fallopian tubes, normal uterine anatomy, and functional tubes, increasing the number of eggs produced in a given cycle increases the probability of conception. In these patients, use of ovulation-inducing agents is aimed at producing multiple eggs in a given cycle (superovulation), in order to increase the chances of conception. Given these very different patient populations and therapeutic goals, we began our review by separating included studies between those which specifically corrected anovulation in women with PCOS and those which involved superovulation in women with normal ovulatory function.

For each category of patient, we further divided studies by the types of intervention used. For anovulatory women, these were: (a) inhibitors of estrogen action (including anti-estrogens such as clomiphene citrate, e.g., Clomid®, and aromatase inhibitors such as letrozole; as a group, we refer to these as estrogen inhibitors); (b) insulin sensitizers (such as metformin, or Glucophage^®^); (c) gonadotropins (such as human menopausal gonadotropins, e.g., Pergonal®); (d) combination therapies; and (e) surgical therapies. For ovulatory women, we used the same categories, with the exception of insulin sensitizers. Since intrauterine insemination (IUI) is often included as part of the ovulation induction or superovulation regimen, we also included studies which addressed specific aspects of IUI in each group.

As described in the Methods chapter, we excluded all non-randomized studies, as well as “quasi-randomized” studies (such as those where treatment assignment was based on alternate history numbers or clinic days). For this topic, the primary outcome of interest was the cumulative number of clinical pregnancies or, preferably, live births per couple; wherever possible, we used the number of women/couples randomized as the denominator. We excluded any study where these outcomes were not reported or calculable from the presented results. Some studies used crossover designs. Because a crossover design requires the assumption that all cycles are equivalent, and ignores the implications of different pregnancy rates in the first cycle on the subjects in the second cycle, interpretation of the results of crossover studies of infertility treatments is extremely problematic.^36^ Therefore, we included crossover studies only if the results for the first cycle were presented separately.

For the primary outcomes, relative risks (RRs) with 95 percent confidence intervals (CIs) were calculated from the presented results. Because of substantial clinical heterogeneity in the studies in terms of patient characteristics (such as body mass index [BMI] in studies of PCOS) and treatment regimens, we did not perform formal meta-analyses.

Results for other outcomes, such as multiple pregnancy or spontaneous abortion rates, are summarized in the text. The majority of included studies were extremely limited in power to detect differences in the primary outcomes, let alone any differences in other less common outcomes. Outcomes related to later pregnancy and longer term maternal and child outcomes are discussed under Question 4.

Please note that in the summary tables throughout this chapter, estimates of relative effect with CIs that do not cross 1 (i.e., estimates that are statistically significant) are bolded for emphasis.

### III. Search Results

The flow of articles on this topic through the literature search and screening process is depicted in Figure 3.

Figure 3. Literature flow diagram - Question 2

### IV. Induction of Ovulation in Anovulatory Women

A. Drugs for inducing ovulation-estrogen inhibitors. PCOS is a condition marked by anovulation, hyperandrogenism, and insulin resistance. Common clinical manifestations include oligo- or amenorrhea, acne, hirsutism, and obesity.^42^ The mainstay of treatment for many years has been clomiphene citrate (CC); clomiphene is a non-steroid which chemically resembles tamoxifen, and, like tamoxifen, it has both estrogen agonist and antagonist effects at the level of the estrogen receptor; it promotes the release of follicle-stimulating hormone (FSH) from the pituitary, with subsequent follicular development and ovulation in the ovary.^43^ Trials prior to 2000 demonstrated that clomiphene is superior to placebo in achieving pregnancy in anovulatory women.^44^

Recently, another class of estrogen inhibitors, aromatase inhibitors, has been explored as an alternative for ovulation induction. These agents, which have been shown to have efficacy in breast cancer patients, work by preventing the conversion of testosterone to estrogen via the enzyme aromatase.

This section reviews studies where estrogen inhibitors were the sole treatments for infertile women with PCOS. Studies where they are compared to other classes of agents, or studies with combination therapies, are described below.

1. Included studies. Five studies met our inclusion criteria (Table 4). All five had fewer than 50 subjects per arm, only two followed subjects for more than one cycle, and none reported live births.

Table 4 Estrogen inhibitors alone in anovulation

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Clomiphene vs. other estrogen inhibitors
Boostanfar et al., 2001^45^ | Reference | Clomiphene | 40
Boostanfar et al., 2001^45^ | | Tamoxifen | 46 | 1.30 | 0.51 | 3.35 | - | - | -
| | Cycles/patient: 2.4
Wu et al., 2007^46^ | Reference | Clomiphene | 19
Wu et al., 2007^46^ | | Anastrozole | 14 | 5.68 | 0.27 | 119 | - | - | -
| | Cycles/patient: 1.0
Bayar et al., 2006^47^ | Reference | Clomiphene | 36
Bayar et al., 2006^47^ | | Letrozole | 38 | 1.45 | 0.60 | 3.53 | - | - | -
| | Cycles/patient: 2.7
Timing of clomiphene administration
Dehbashi et al., 2006^48^ | Reference | Clomiphene days 5–9 | 41
Dehbashi et al., 2006^48^ | | Clomiphene days 1–5 | 37 | 2.08 | 1.00 | 4.33 | - | - | -
| | Cycles/patient: 1.9

In direct comparisons of estrogen inhibitors, the small sample sizes of comparisons of clomiphene to tamoxifen,^45^ anastrozole,^46^ and letrozole^47^ result in wide confidence intervals for treatment efficacy.

Based on one small study, administration of clomiphene on cycle days 1–5 results in a significantly higher cumulative pregnancy rate than administration on cycle days 5–9 (RR 2.08; 95 percent CI 1.00–4.33).^48^

None of the studies had sufficient numbers to draw any conclusions regarding other outcomes such as spontaneous abortion or multiple pregnancies.

2. Other published systematic reviews. In one published systematic review of clomiphene versus tamoxifen^49^ involving four studies (three pre-2000) with a total of 243 subjects and 743 cycles, there was no significant difference in pregnancy rate per cycle (RR 1.06; 95 percent CI 0.58–1.91); pregnancy or live birth per couple were not calculable.

3. Cochrane reviews. The most recent Cochrane update was in November 2004.^44^ Other than showing superiority of clomiphene to placebo, no comparison (tamoxifen vs. clomiphene, clomiphene plus tamoxifen vs. clomiphene alone, or letrozole vs. anastrozole) had sufficient numbers of patients to be able to reach any conclusions regarding relative efficacy in achieving pregnancy (Table 5).

Table 5 Cochrane review, estrogen inhibitors alone in anovulation^44^

Interventions | | N | Efficacy
Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Relative Effect | Lower 95% CI | Upper 95% CI | Relative Effect | Lower 95% CI | Upper 95% CI
Clomiphene vs. placebo
Reference | Placebo | 63
| Clomiphene | 70 | 5.77 | 1.55 | 21.5 | - | - | -
| 3 studies, all pre-2000
Clomiphene vs. tamoxifen
Reference | Tamoxifen | 91
| Clomiphene | 90 | 1.00 | 0.48 | 2.09 | - | - | -
| 2 studies, 1 post-2000
Clomiphene + tamoxifen vs. clomiphene
Reference | Clomiphene | 10
| Clomiphene + tamoxifen | 10 | 3.32 | 0.12 | 91.6 | - | - | -
| 1 study, pre-2000
Letrozole vs. anastrozole
Reference | Anastrozole | 18
| Letrozole | 22 | 1.88 | 0.40 | 8.88 | - | - | -
| 1 study, post-2000

4. Conclusions. Clomiphene citrate is superior to placebo in achieving pregnancy in anovulatory women; as such, it is a reasonable reference treatment for evaluation of other methods for induction of ovulation in this patient population. There is insufficient evidence to allow any inferences regarding the relative efficacy of other estrogen inhibitors compared to clomiphene.

B. Drugs for inducing ovulation - insulin-sensitizers. Interventions that improve insulin resistance, such as weight loss or treatment with specific drugs in women with PCOS can also lead to decreases in circulating androgens and ovulation. The most commonly used agent has been metformin; the most recent Cochrane review found significantly increased rates of ovulation with metformin compared to placebo (odds ratio [OR] 3.88; 95 percent CI 2.26–6.69).^50^ A different class of insulin sensitizers, the thiazolidinediones, have also been investigated, although one agent that increased ovulation rates in PCOS patients in a randomized controlled trial (RCT), troglitazone,^51^ has subsequently been removed from the market due to hepatic toxicity. Potential advantages of insulin sensitizers for induction of ovulation compared to estrogen inhibitors or gonadotropins include correction of underlying metabolic abnormalities which may have adverse longer term cardiovascular consequences^52^ and reduced rates of multiple gestation. Although neither class of drugs is approved for use in pregnancy, there are enough data available for metformin to be placed in the U.S. Food and Drug Administration (FDA) Pregnancy Category B (human data reassuring), while thiazoledinediones are in Category C (insufficient data).^53^

Although efficacy in establishing ovulation has been established, at least for metformin, the evidence available at the time of the Cochrane review was limited for pregnancy and live birth.^50^ This section reviews the literature meeting our search criteria that provided data on pregnancy and live birth rates.

1. Included Studies. The following sections describe studies comparing metformin to placebo, metformin to other insulin sensitizers, and metformin to clomiphene. Studies that compared metformin in combination with other agents are described in the section on combination therapy.

We identified three studies^54^–^56^ comparing metformin to placebo that met our search criteria (Table 6). All three studies were small, ranging in size from 20 to 56 subjects. Two studies, one in new patients^54^ and one in patients who had previously failed to ovulate with clomiphene treatment,^55^ had non-significant increases in pregnancy rates; the third trial^56^ had only three pregnancies in 20 subjects.

Table 6 Insulin sensitizers in anovulation

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Metformin vs. placebo
Fleming et al., 2002^54^ | Reference | Placebo | 19
Fleming et al., 2002^54^ | | Metformin | 23 | 3.30 | 0.40 | 27.1
| | | Subgroup of patients actively seeking pregnancy; cycles/patient: > 1
Kocak et al., 2002^55^ | Reference | Placebo | 28
Kocak et al., 2002^55^ | | Metformin | 28 | 6.00 | 0.31 | 114
| Clomiphene-resistant | | Cycles/patient: > 1
Ng et al., 2001^56^ | Reference | Placebo | 10
Ng et al., 2001^56^ | | Metformin | 10 | 0.50 | 0.05 | 4.67
| Clomiphene-resistant | | Cycles/patient: > 1
Metformin vs. other sensitizers
Rouzi and Ardawi, 2006^57^ | Reference | Metformin | 13
Rouzi and Ardawi, 2006^57^ | | Rosiglitazone | 12 | 1.30 | 0.53 | 3.17 | 1.35 | 0.47 | 3.89
| | | Cycles/patient: > 1
Ortega-Gonzalez et al., 2005^58^ | Reference | Metformin | 27
Ortega-Gonzalez et al., 2005^58^ | | Pioglitazaone | 25 | | | | 1.80 | 0.48 | 6.76
| | | Cycles/patient: 6 months; not designed as infertility study
Metformin vs. clomiphene
Palomba et al., 2005^59^ | Reference | Clomiphene + placebo | 50
Palomba et al., 2005^59^ | | Metformin + placebo | 50 | 3.10 | 1.71 | 5.62 | 2.80 | 1.53 | 5.13
| | | Cycles/patient 4.2
Legro et al., 2007^6^ | Reference: | Clomiphene + placebo | 209
Legro et al., 2007^6^ | | Metformin + placebo | 203 | 0.36 | 0.22 | 0.60 | 0.33 | 0.19 | 0.57
Legro et al., 2007^6^ | | Clomiphene + metformin | 209 | 1.30 | 0.95 | 1.78 | 1.19 | 0.85 | 1.67
| | | Cycles/patient: 4.7; multiples only in clomiphene arms

Two small studies compared metformin to rosiglitazone^57^ or pioglitazone^58^(Table 6). Neither study had sufficient power to demonstrate any difference in pregnancy or live birth rates, and the study by Ortega-Gonzalez and colleagues^58^ was not designed as an infertility trial.

Two RCTs provided data which allowed direct comparison of metformin to clomiphene^6,59^(Table 6). Both studies used a double-blind, double-dummy design, where women received either clomiphene plus placebo “metformin,” or metformin plus placebo “clomiphene,” and continued treatment for up to 6 months.

In a single center study, Palomba and colleagues randomized 50 women to each arm. The primary outcome was pregnancy rate, and the study was powered to detect a 30 percent absolute difference. Both ovulation and pregnancy rates were higher in the first two cycles with clomiphene, but higher with metformin in subsequent cycles.^59^ Cumulative ovulation rates were similar (62.9 percent with metformin vs. 67 percent for clomiphene), but cumulative and ongoing pregnancy rates were significantly higher with metformin (RR for cumulative pregnancy rates 3.10; 95 percent CI 1.71–5.62; for ongoing pregnancy, RR 2.80; 1.53–5.13). Spontaneous abortion rates were higher in the clomiphene group. There were no multiple pregnancies in either arm, and no clear difference in pregnancy complications.

Contrasting results were found in a larger multi-center trial, the Pregnancy in Polycystic Ovary Syndrome (PPCOS) study, conducted by Legro and colleagues.^6^ This trial also included a third arm of active clomiphene plus metformin; these results are discussed separately in the combination therapy section. Randomization was stratified by center and history of prior therapy with either metformin or clomiphene (approximately 60 percent of subjects had previously received at least one of the experimental treatments, with 18 percent having received both). The primary outcome was live birth, powered to detect an absolute difference of 15 percent. Six hundred twenty-six women were randomized. Ovulation rates were significantly higher in the clomiphene only group compared to metformin (49 percent vs. 29 percent), and both pregnancy and live birth rates were substantially higher in the clomiphene only group (RR for live birth 0.33; 95 percent CI 0.19–0.57). There were three multiple pregnancies in the clomiphene-only group, none in the metformin group, with a non-significant trend towards higher pregnancy loss rates in the metformin group; there were no clear differences in pregnancy complications. Overall side effects were similar, with hot flashes and vaginal symptoms more common with clomiphene, and gastrointestinal symptoms more common with metformin.

From the published data, there is no clear explanation for the discrepant results of these two similarly designed studies. The main differences in the subject populations were prior treatment (none in the Palomba study, 60 percent in PPCOS) and BMI (restricted to less than 30 kg/m^2^ in the Palomba study, while almost 20 percent of the PPCOS subjects had a BMI between 30 and 34 kg/m^2^, and almost 50 percent had a BMI of 35 kg/m^2^ or above). However, because of the large sample size and randomized design, these factors were equally distributed between treatment arms. In addition, post-hoc analyses based on BMI and history of prior treatment showed similar results for the comparison of metformin to clomiphene alone. Given the single center European setting versus the multi-center U.S. setting, and subsequent findings of genetic variability in response to metformin,^60^ it is possible that variations in the distribution of relevant genes in different patient populations contributed to some of the difference.

2. Other published systematic reviews. We identified one published non-Cochrane review by Kashyap and colleagues.^61^ This review identified two studies with a total of 65 subjects comparing metformin to placebo, with a summary odds ratio of 1.07 (95 percent CI 0.20–5.74).

3. Cochrane reviews. The most recent Cochrane update was in December 2002.^50^ Based on five studies with a total of 172 subjects, pregnancy rates were increased non-significantly with metformin compared to no treatment or placebo (OR 2.76; 95 percent CI 0.85–8.98); only two of these studies (n = 50) reported live birth rates (OR 1.00; 0.13–7.79).

4. Conclusions. Although the majority of randomized studies suggest that pregnancy rates are increased with metformin compared to placebo, the small number of trials, along with the small size of the trials, means that the results are non-significant for both individual studies and meta-analyses performed to date.

There is insufficient evidence to compare the efficacy of available thiazolidinediones to placebo, metformin, or any other currently used agent for induction of ovulation in women with PCOS.

Results of the two direct randomized comparisons of metformin to clomiphene are contradictory. The smaller single center study found metformin superior to clomiphene in achieving pregnancy, while a much larger multi-center study found clomiphene superior to metformin in achieving both pregnancy and live birth, results that were consistent regardless of BMI or history of prior therapy. Results for spontaneous abortion rates were similarly discrepant. Multiple pregnancies were only observed in women treated with clomiphene. Based on this evidence, we conclude that metformin is, at best, not superior to clomiphene in achieving pregnancy and live birth, and, based on the largest study, is inferior. Sample sizes are too small in the randomized trials to draw conclusions about spontaneous abortion or other pregnancy-related outcomes.

C. Drugs for inducing ovulation - gonadotropins. Approximately 20–40 percent of women with PCOS will fail to conceive in response to clomiphene.^62,63^ One option for treating these women is stimulation with exogenous gonadotropins. Although effective in achieving pregnancy, there is an increased risk of both multiple pregnancies and ovarian hyperstimulation syndrome (OHSS).^64^ The purpose of studies of variation in the type and/or dosing of gonadotropin is to determine optimal pregnancy and live births while minimizing multiple births and OHSS. This section reviews the existing evidence on the efficacy of various approaches to ovulation induction using gonadotropins in PCOS patients.

1. Included studies. The six identified studies are shown in Table 7. None of the studies had adequate power to detect differences in pregnancy rate. Because multiples and OHSS will be even less frequent than pregnancy, these studies were not able to provide any conclusive evidence regarding any gonadotropin-based method.

Table 7 Gonadotropins alone in PCOS

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Dosage
Balasch et al., 2001^65^ | Reference | rFSH step-down | 14
Balasch et al., 2001^65^ | | rFSH step-up | 15 | 1.87 | 0.19 | 18.4
| Clomiphene-resistant | | Cross-over design - 1^st^ cycle only
Christin-Maitre et al., 2003^66^ | Reference | rFSH step-down | 39
Christin-Maitre et al., 2003^66^ | | rFSH step-up | 44 | 1.26 | 0.69 | 2.29
| Clomiphene-resistant | | Cycles/patient: 1.9; multiple gestations 0.59 (010, 3.35)
Leader and Monofollicular Ovulation Induction Study Group, 2006^67^ | Reference | 25 IU rFSH step-up | 83
Leader and Monofollicular Ovulation Induction Study Group, 2006^67^ | | 50 IU rFSH step-up | 78 | 0.67 | 0.32 | 1.38
| Clomiphene-resistant | | Cycles/patient: 1.0; multiples 0.26 (0.01, 5.8); ovarian hyperresponse 4.26 (1.49, 12.2)
Type of gonadotropin
Gerli et al., 2004^68^ | Reference: | rFSH | 88
Gerli et al., 2004^68^ | | Urinary FSH | 82 | 1.03 | 0.62 | 1.69
| | | Cycles/patient: 2.23; multiples 0.91 (0.21, 4.00)
Revelli et al., 2006^69^ | Reference: | rFSH | 35
Revelli et al., 2006^69^ | | Highly purified urinary FSH | 39 | | | | 0.51 | 0.16 | 1.63
| Clomiphene-resistant | | Cycles/patient: 1.0; fewer vials of rFSH used - lower cost
Timmerman-van Kessel et al., 2000^70^ | Reference: | Clomiphene | 12
Timmerman-van Kessel et al., 2000^70^ | | Pulsatile GnRH | 16 | 0.75 | 0.23 | 2.41
| Clomiphene-resistant | | Cycles/patient: 2.1

2. Other systematic reviews. We did not identify any other non-Cochrane published reviews.

3. Cochrane reviews. There are three relevant Cochrane reviews. The first^71^ was most recently updated in May 2000 and reviewed studies of gonadotropin therapy in PCOS. All studies were published prior to 2000, and neither pregnancy nor live birth per couple was reported or calculable. In five studies, FSH alone resulted in lower OHSS compared to human menopausal gonadotropins (hMG) when no gonadotropin-releasing hormone (GnRH) analog was used (OR 0.20; 95 percent CI 0.08–0.46); when GnRH agonists were used, overstimulation requiring cycle cancellation was significantly more frequent. OHSS was increased, but the confidence intervals for the OR include 1.0.

The second review^72^ was most recently updated in February 2001 and compared recombinant (rFSH) versus urinary FSH (uFSH) preparations. Using urinary FSH as the reference, there was no significant difference in pregnancy rate (OR 0.95; 95 percent CI 0.64–1.41), multiple gestations (0.44; 0.16, 1.21), or OHSS (1.55; 0.50, 4.84). Only one study (pre-2000) of different dosing regimens was included in the review. It compared a conventional regimen guided by ovarian response versus chronic low-dose rFSH and found non-significant differences in pregnancy rates (OR 1.62; 95 percent CI 0.65–4.07).

The third review of pulsatile GnRH administration^73^ included only the study of Timmerman et al.;^70^ with only 30 subjects, this study, like the majority of the others, was not powered to detect meaningful differences in pregnancy rates.

4. Conclusions. Based on pre-2000 studies included in the Cochrane review,^71^ use of FSH results in a lower incidence of OHSS compared with hMG, particularly if there is no concomitant pituitary suppression. There is insufficient evidence to determine the most effective form or regimen for administration of FSH for ovulation induction in women with PCOS who do not respond to clomiphene.

D. Drugs for inducing ovulation - combinations. Combinations of all three of the major classes of medical treatments for PCOS have been tested, along with other adjunctive therapies, both as primary treatment for PCOS and in women who fail to respond to a trial of clomiphene. This section describes studies that tested combinations of medical therapies, divided broadly by studies of first-line treatment and treatments in clomiphene-resistant women.

1. Included studies: first-line treatment. Summary RRs for included studies are shown in Table 8. Two studies compared metformin plus clomiphene to monotherapy in patients receiving initial therapy for infertility associated with PCOS. Moll and colleagues^74^ randomized 225 women to clomiphene plus placebo or clomiphene plus metformin and found no difference in pregnancy rates (RR 0.87; 95 percent CI 0.64–1.18). In the previously described PPCOS study,^6^ clomiphene plus metformin was significantly more effective in achieving both pregnancy and live birth than metformin alone; live birth rates were increased, but not significantly, compared to clomiphene alone (RR 1.19; 0.85–1.67). This effect was seen in women with and without prior therapy. In another subgroup analysis, any benefit of adding metformin to clomiphene was limited to women with a BMI greater than or equal to 35, although the sample size was not sufficient to show statistical significance.

Table 8 Combination therapy as first-line-treatment in anovulation

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Clomiphene + metformin
Moll et al., 2006^74^ | Reference | Clomiphene + placebo | 114
Moll et al., 2006^74^ | | Clomiphene + metformin | 111 | 0.87 | 0.64 | 1.18 | - | - | -
| | | Cycles/patient: > 1.0
Legro et al., 2007^6^ | Reference | Clomiphene + placebo | 209
Legro et al., 2007^6^ | | Metformin + placebo | 203 | 0.36 | 0.22 | 0.60 | 0.33 | 0.19 | 0.57
Legro et al., 2007^6^ | | Clomiphene + metformin | 209 | 1.30 | 0.95 | 1.78 | 1.19 | 0.85 | 1.67
| | | Cycles/patient: 4.7; multiples only in clomiphene arms
Clomiphene + hCG trigger
George et al., 2007^75^ | Reference | Clomiphene | 90
George et al., 2007^75^ | | Clomiphene + hCG trigger | 90 | 1.67 | 0.63 | 4.39 | 1.60 | 0.54 | 4.70
| | | Cycles/patient: 1.0??
Yilmaz et al., 2006^76^ | Reference | Clomiphene citrate | 60
Yilmaz et al., 2006^76^ | | Clomiphene + hCG as trigger | 65 | 1.20 | 0.71 | 2.05 | - | - | -
| | | Cycles/patient: 1.0; multiples 2.17 (0.20, 23.3)
Clomiphene + ketoconazole
Ali Hassan et al., 2001^79^ | Reference | Clomiphene | 48
Ali Hassan et al., 2001^79^ | | Clomiphene + ketoconazole | 49 | 2.08 | 0.99 | 4.36 | 2.24 | 1.01 | 4.95
| | | Cycles/patient: 3.3; multiples 0.63 (0.33, 1.19); more dropouts in clomiphene-only group
Clomiphene + estrogens
Unfer et al., 2004^78^ | Reference | Clomiphene | 69
Unfer et al., 2004^78^ | | Clomiphene + phytoestrogen | 65 | 1.77 | 0.83 | 3.76 | 4.60 | 1.37 | 15.4
| | | Cycles/patient: 1.0; spontaneous abortion rate lower in CC + estrogen group
Gerli et al., 2000^77^ | Reference | Clomiphene | 32
Gerli et al., 2000^77^ | | Clomiphene + estradiol | 32 | 1.75 | 0.85 | 3.59 | 6.00 | 1.46 | 24.6
| | | Cycles/patient: 1.0; spontaneous abortion rates lower in clomiphene + estradiol group (0.33; 95% CI 0.07, 1.53)

Two studies compared clomiphene alone to clomiphene with ultrasound monitoring of the ovaries and triggering of ovulation with human chorionic gonadotropin (hCG), followed by intercourse.^75,76^ Pregnancy rates were increased in both, but not significantly (Table 8).

In one small study, the addition of ketoconazole to clomiphene resulted in significantly more live births (RR 2.24; 95 percent CI 1.01–4.95), with a trend towards reduced multiple pregnancies. This study was published in 2001, and we did not identify any subsequent similar studies in our search.

Because clomiphene has both agonist and antagonist effects on the estrogen receptor, depending on the target tissue, failure to conceive or early pregnancy loss in some women receiving clomiphene may be due to estrogen inhibiting effects in other sites in the reproductive tract. Two studies evaluating the addition of estrogens, either ethinyl estradiol^77^ or phytoestrogens,^78^ found significantly increased live birth rates compared to clomiphene alone (RRs of 4.6 and 6.0), with decreased spontaneous abortion rates. Again, we did not identify any other studies that would confirm these results.

2. Included studies: second-line treatment after initial failure with clomiphene. Summaries of study size and RRs are presented in Table 9.

Table 9 Combination therapy in women who fail initial treatment with clomiphene

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Clomiphene + insulin sensitizers
George et al., 2003^88^ | Reference | Metformin × 6 months, followed by clomiphene | 30
George et al., 2003^88^ | | hMG | 30 | 1.40 | 0.50 | 3.92 | 3.00 | 0.66 | 13.7
| Clomiphene-resistant | | Cycles/patient: > 1.0
Ghazeeri et al., 2003^82^ | Reference | Rosiglitazone + placebo | 12
Ghazeeri et al., 2003^82^ | | Rosiglitazone + clomiphene | 13 | 1.85 | 0.19 | 17.9 | 0.92 | 0.06 | 13.2
| Clomiphene-resistant
Malkawi et al., 2002^80^ | Reference | Clomiphene + placebo | 12
Malkawi et al., 2002^80^ | | Clomiphene + metformin | 16 | 3.30 | 0.89 | 12.8 | - | - | -
| Clomiphene-resistant | | Cycles/patient: 2.7
Vandermolen et al., 2001^81^ | Reference | CC + placebo | 15
Vandermolen et al., 2001^81^ | | CC + metformin | 12 | 7.50 | 1.04 | 54.1 | - | - | -
| Clomiphene-resistant
Gonadotropins + insulin sensitizers
Yarali et al., 2002^83^ | Reference | FSH + placebo | 15
Yarali et al., 2002^83^ | | FSH + metformin | 16 | 4.69 | 0.62 | 35.6 | - | - | -
Yarali et al., 2002^83^ | | | | Cycles/patient: 1.0
| Clomiphene-resistant
Palomba et al., 2005^84^ | Reference | COH only | 35
Palomba et al., 2005^84^ | | COH + metformin | 35 | 1.29 | 0.77 | 2.16 | 1.42 | 0.80 | 2.51
| Non-obese; insulin-resistant; clomiphene-resistant | | Cycles/patient: 2.45; multiples 0.51 (0.02, 15.0); OHSS 0.31 (0.07, 1.37)
Clomiphene + oral contraceptive pre-treatment
Branigan and Estes, 2003^85^ | Reference | Clomiphene + hCG trigger | 24
Branigan and Estes, 2003^85^ | | Pre-treatment with OCP + clomiphene + hCG trigger | 24 | 13.0 | 1.84 | 91.7 | - | - | -
| Clomiphene-resistant | | Cycles/patient: 1.9; multiples increased with OCPs
Clomiphene + hCG trigger
Branigan and Estes, 2005^89^ | Reference | Clomiphene 100 mg | 36
Branigan and Estes, 2005^89^ | | Clomphene 50 mg + hCG ovulation trigger | 35 | 6.38 | 0.35 | 126 | - | - | -
| Clomiphene-resistant | | Cycles/patient: 1.0
Clomiphene + other agents
Rizk et al., 2005^86^ | Reference | Clomiphene + placebo | 75
Rizk et al., 2005^86^ | | Clomiphene + n-acetyl-cysteine | 75 | 28.8 | 1.7 | 488 | - | - | -
| Clomiphene-resistant | | Cycles/patient: 1.0; multiple gestation 10.3 (0.6, 189.8)
Elnashar et al., 2006^87^ | Reference | Clomiphene + placebo | 40
Elnashar et al., 2006^87^ | | Clomiphene + dexamethasone | 40 | 8.00 | 1.97 | 32.5 | - | - | -
| Clomiphene-resistant | | Cycles/patient: 1.0

Two small studies^80,81^ suggest an improvement in pregnancy rates with the addition of metformin in women who have previously failed clomiphene treatment, although individual differences were not statistically significant. Another small study failed to show a significant difference with the addition of rosiglitazone.^82^

Metformin also non-significantly increased pregnancy rates in two studies of gonadotropin use.^83,84^

Three studies of different adjunct therapies demonstrated large and statistically significant improvements in pregnancy rates in clomiphene-resistant women compared to clomiphene alone: pre-treatment with oral contraceptives^85^(RR 13.0; 95 percent CI 1.84–97.0); co-administration of n-acetyl-cysteine^86^(RR 28.0; 1.7–488); and co-administration of dexamethasone^87^(RR 8.00; 1.97–32.5). Of note, multiple gestation rates were increased with all three approaches. As is evident from the width of the confidence intervals, the combination of relatively small study size and lower event rates prevents precise estimates of efficacy, but the effect size for all suggests that further studies of each of these approaches with a focus on minimizing multiple gestation risk are warranted.

3. Other systematic reviews. One published non-Cochrane systematic review^61^ found an increased pregnancy rate with clomiphene plus metformin compared to clomiphene plus placebo in clomiphene-resistant women (OR 3.65; 95 percent CI 1.11–12.0).

The relevant Cochrane review^44^(Table 10) showed significantly increased pregnancy rates with use of clomiphene plus dexamethasone (OR 11.3; 95% CI 5.33–24.1) and clomiphene after pre-treatment with oral contraceptives (OR 26.7; 4.91–145); both of these treatments also had substantial increases in multiple pregnancy rates, although confidence intervals included 1.0. The addition of metformin to gonadotropins was also superior to gonadotropins alone for pregnancy (OR 4.88; 2.46–9.67).

Table 10 Cochrane review, combination therapies in clomiphene-resistant women^44^

Interventions | | N | Efficacy
Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Effect | Lower 95% CI | Upper 95% CI | Rel Effect | Lower 95% CI | Upper 95% CI
Clomiphene + bromocryptine vs. clomiphene
Reference | Clomiphene | 53
| Clomiphene + bromocryptine | 47 | 0.98 | 0.33 | 2.96 | - | - | -
| 1 study, post-2000
Clomiphene + dexamethasone vs. clomiphene
Reference | Clomiphene | 141
| CC + dexamethasone | 134 | 11.3 | 5.33 | 24.1 | - | - | -
| 2 studies, 1 post-2000 | | Multiples (1 study), 7.68 (0.37, 157)
Clomiphene + ketoconazole vs. clomiphene
Reference | Clomiphene | 37
| CC + ketonazole | 43 | 2.37 | 0.88 | 6.40 | - | - | -
| 1 study, post-2000
Clomiphene + OCPs vs. clomiphene
Reference | Clomiphene | 24
| Clomiphene + OCPs | 24 | 26.7 | 4.91 | 145 | - | - | -
| 1 study, post-2000 | | Multiples 7.98 (0.39, 163)
Metformin + ovulation induction vs. ovulation induction alone
Reference | Ovulation induction | 109
| Metformin + induction | 110 | 4.88 | 2.46 | 9.67 | 5.48* | 0.81 | 37.3
| 5 studies, all post-2000 | | *1 study, post-2000, n = 27

4. Conclusions. Based on two large randomized trials, the addition of metformin to clomiphene as first-line therapy does not appear to significantly increase pregnancy or live birth rates, although a subgroup analysis of the largest trials suggests that there may be benefit in women with a BMI greater than or equal to 35, a finding which should be confirmed in a larger study.

The addition of ketoconazole (one study) and estrogens (two studies) to clomiphene in first-line therapy resulted in significantly increased live birth rates due to decreased spontaneous abortion rates, findings which should be confirmed in larger trials.

Although a statistically significant effect is not observed in individual studies, meta-analyses do demonstrate a significant increase in pregnancy rates in clomiphene-resistant women treated with metformin. Whether these results translate into improved live birth rates should be confirmed in larger studies, although the lower overall birth rate in this population will require large studies.

Pre-treatment with oral contraceptives, co-treatment with n-acetyl-cysteine, and co-treatment with dexamethasone all resulted in large and statistically significant increases in pregnancy rates in combination with clomiphene in clomiphene-resistant anovulatory women, along with increased multiple gestation rates. These findings warrant further investigation, particularly if multiple gestation can be avoided.

E. Surgical procedures for inducing ovulation. One of the earliest treatments for PCOS was wedge resection of the ovary, which, while effective in inducing ovulation, had attendant surgical risks, as well as the risk of developing adhesions.^90^ With the advent of laparoscopic surgical procedures, both short- and long-term risks are theoretically lower. Several studies have investigated the role of laparoscopic “drilling” of the ovary using electrocautery.

1. Identified studies. Identified studies are summarized in Table 11. The largest study, by Bayram and colleagues,^91^ compared a strategy of immediate gonadotropins to laparoscopic electrocautery, followed by ovulation induction agents only if pregnancy did not occur. The electrocautery strategy resulted in similar pregnancy and live birth rates (live birth RR 1.14; 95 percent CI 0.94–1.39) with significantly lower multiple gestation rates (RR 0.11; 0.01–0.88). In another study in a similar population, Palomba and colleagues found significantly higher pregnancy and live birth rates with the addition of metformin after laparoscopic cautery.^92^ None of the studies had sufficient followup to assess the risk of longer term complications such as adhesions or premature ovarian failure.

Table 11 Surgical interventions for anovulatory infertility

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Bayram et al., 2004^91^ | Reference | rFSH | 85
Bayram et al., 2004^91^ | | Electrocautery followed by ovulation induction if necessary | 83 | 1.14 | 0.94 | 1.39 | 1.14 | 0.94 | 1.39
| Clomiphene-resistant | | Multiples 0.11 (0.01, 0.88)
Palomba et al., 2005^93^ | Reference | Laparoscopic drilling + clomiphene | 20
Palomba et al., 2005^93^ | | Metformin × 6 months + clomiphene | 8 | 1.25 | 0.73 | 2.98 | 1.43 | 0.54 | 3.57
| Clomiphene-resistant; anovulatory after metformin or drilling | | Cycles/patient: 3.9
Palomba et al., 2005^93^ | Reference | Laparoscopic drilling + clomiphene | 20
Palomba et al., 2005^93^ | | Metformin × 6 months + clomiphene | 8 | 1.25 | 0.73 | 2.98 | 1.43 | 0.54 | 3.57
| Clomiphene-resistant; anovulatory after metformin or drilling | | Cycles/patient: 3.9
Palomba et al., 2004^92^ | Reference | Laparoscopic ovarian diathermy + placebo | 60
| Laparoscopic ovarian diathermy + metformin | 60 | 1.60 | 1.04 | 2.46 | 1.60 | 1.04 | 2.46
Farquhar et al., 2002^94^ | Reference | Gonadotropins | 21
| Laparoscopic drilling | 29 | 0.83 | 0.36 | 1.93 | 0.72 | 0.20 | 2.57
Sharma et al., 2006^95^ | Reference | Unilateral drilling | 10
| Bilateral drilling | 10 | 1.40 | 0.67 | 2.94 | - | - | -

2. Other systematic reviews. We did not identify any non-Cochrane published reviews.

3. Cochrane reviews. The relevant Cochrane review^96^ concluded that laparoscopic drilling, with or without stimulation, resulted in essentially equivalent pregnancy (OR 1.08; 95 percent CI 0.69–1.71) and live birth rates (OR 1.04; 0.59–1.85), with a significantly reduced risk of multiple gestation (OR 0.13; 0.03–0.52).

4. Conclusions. Use of laparoscopic cautery, followed by ovulation induction if necessary, results in similar pregnancy and live birth rates, with significantly lower multiple gestation rates, compared to immediate gonadotropin use in clomiphene-resistant women. The addition of metformin may result in further improvements in pregnancy and live birth rates. There are no data on the long-term sequelae of laparoscopic ovarian cautery.

F. Aspects of intrauterine insemination in anovulatory women. Intrauterine insemination (IUI) may be used as an adjunct to ovulation induction in women with PCOS, although we did not identify any recent randomized trials that directly compared ovulation induction with and without IUI.

1. Identified studies. We identified one study that addressed aspects of IUI in this population. Lewis and colleagues^97^ compared two methods for the timing of IUI - one with home monitoring of urinary luteinizing hormone (LH), with IUI after detection of the LH surge, versus ultrasound monitoring of follicular development and triggered ovulation using hCG, followed by IUI. Pregnancy rates were increased with hCG triggering, but not significantly (RR 1.73; 95 percent CI 0.88–3.38).

2. Other systematic reviews. Kosmas and colleagues,^98^ in a systematic review of timing of IUI based on LH monitoring versus hCG triggering, found non-significantly increased pregnancy rates with hCG triggering after clomiphene treatment in anovulatory patients (OR 2.00; 95 percent CI 0.84–4.77)

3. Cochrane reviews. There were no relevant Cochrane reviews.

4. Conclusions. Although the available studies suggest an increase in pregnancy rates with hCG triggering for IUI after ovulation induction with clomiphene in women with PCOS, sample sizes have been too small to demonstrate statistically significant differences. Given the large differences in cost, patient convenience, and the fairly high relative rates (1.7–2.0) observed between these two treatments, definitive determination of superiority should be a research priority.

### V. Superovulation in Ovulatory Women

For couples where the female partner has normal ovulatory function and at least one patent fallopian tube, and the male partner has motile sperm, superovulation (use of gonadotropins to induce development of more than one follicle in a given cycle), followed by IUI, is the most efficient method of treatment, resulting in 2–3 times higher pregnancy and live birth rates within 6 months of treatment compared to IUI alone, intracervical insemination (ICI) alone, or superovulation with ICI.^99^ However, this increased probability is associated with an increased risk of multiple gestations, which are at risk of multiple complications, including preterm birth and its sequelae; in the trial cited above, 16 percent of the live births in the two superovulation arms were preterm, compared to 6 percent of those in the other two arms (RR 2.60; 95 percent CI 0.79–8.61).

This section reviews publications subsequent to this study that address methods for superovulation, largely with IUI, as therapy in infertile couples where the female partner has normal ovulatory function and tubal patency, and where the male partner has motile sperm.

A. Drugs for superovulation-estrogen inhibitors. In theory, estrogen inhibitors should produce similar hypothalamic and pituitary responses in ovulatory women as they do in anovulatory women, leading to the development of multiple follicles and an increased probability of conception. Because estrogen inhibitors are oral agents with a lower risk of higher order multiples than the injectable gonadotropins, and cost significantly less, they are a potentially attractive candidate for superovulation. This section reviews the evidence on the efficacy of estrogen inhibitors and aromatase inhibitors compared to no treatment, to each other, and to gonadotropins.

1. Identified studies. Table 12 summarizes the identified studies. In general, significant differences were not observed in pregnancy rates for any comparison, with the exception of 2.5 mg versus 5.0 mg of letrozole, where the higher dose resulted in large and significant increase in pregnancy rate (RR 4.47; 95 percent CI 1.05–19.0). Although no differences were observed in rates of multiple pregnancy or OHSS, the number of these events in individual studies was small.

Table 12 Estrogen inhibitors, alone and in combination, for superovulation

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Clomiphene vs. aromatase inhibitors
Al-Fozan et al., 2004^100^ | Reference | Clomiphene | 80
Al-Fozan et al., 2004^100^ | | Letrozole | 74 | 1.26 | 0.61 | 2.67 | - | - | -
| All unexplained infertility | | Cycles/patient: 1.8; 25% of all pregnancies ectopic
Fatemi et al., 2003^101^ | Reference | Clomiphene | 8
Fatemi et al., 2003^101^ | | Letrozole | 7 | 0.76 | 0.17 | 3.33 | - | - | -
| | | Cycles/patient: 1.0
Clomiphene plus adjunctive therapy
Badawy et al., 2006^102^ | Reference | Clomiphene + placebo | 400
Badawy et al., 2006^102^ | | Clomiphene + n-acetyl-cysteine | 404 | 0.83 | 0.65 | 1.05 | - | - | -
| | | Cycles/patient: 1.0; multiples 0.66 (0.27,1.60)
Estrogen inhibitor dosing
Al-Fadhli et al., 2006^103^ | Reference | 2.5 mg letrozole | 34
Al-Fadhli et al., 2006^103^ | | 5 mg letrozole | 38 | 4.47 | 1.05 | 19.0 | - | - | -
| | | Cycles./patient: 1.0
Estrogen inhibitors vs. gonadotropins
Baysoy et al., 2006^104^ | Reference | hMG | 40
Baysoy et al., 2006^104^ | | Letrozole | 40 | 1.17 | 0.43 | 3.17 | - | - | -
| Unexplained infertility
| | | | Cycles/patient: ?1.0; multiples 1.00 (0.06, 15.4)
Dankert et al., 2007^105^ | Reference | Clomiphene | 71
Dankert et al., 2007^105^ | | Low-dose rFSH | 67 | 0.90 | 0.58 | 1.41 | 0.95 | 0.55 | 1.64
| | | Cycles/patient: 2.94; multiples and OHSS identical

2. Other systematic reviews. We did not identify any non-Cochrane reviews.

3. Cochrane reviews. There are three relevant Cochrane reviews. The first,^106^ most recently updated in November 2006, reviewed studies of clomiphene versus placebo or no treatment in couples with unexplained infertility; statistically significant differences were not observed, but the overall sample sizes were small, and there was a trend towards higher pregnancy rates when clomiphene was used with IUI (OR 2.40; 95 percent CI 0.70–8.19) or with hCG triggering (OR 1.66; 0.48–4.80). Multiple pregnancy rates were similar (OR 0.99; 0.14–7.12).

The second review,^107^ updated in May 2002, compared clomiphene to gonadotropins. In three studies with a total of 200 subjects, clomiphene had a significantly lower pregnancy rate (OR 0.44; 95 percent CI 0.19–0.99) and a trend towards lower live births (OR 0.51; 0.18–1.47). There was also a trend towards fewer multiple gestations (OR 0.37; 0.06–2.43).

Finally, a review updated in January 2007 compared a variety of protocols for superovulation combined with IUI.^108^ Compared to estrogen inhibitors, gonadotropins resulted in higher pregnancy rates (OR 1.76; 95 percent CI 1.16–2.66) based on seven studies, but there was no difference in live birth rates in the single study that allowed estimation of live birth rates (OR 0.94; 0.44–1.98). Both multiple pregnancy (OR 1.85; 0.53–6.44) and OHSS (OR 4.44; 0.48, 41.3) were more likely with gonadotropins, but, again, because of the relatively low number of these events, confidence intervals include 1.0. In five studies comparing aromatase inhibitors to clomiphene, there was no significant difference in pregnancy rates (OR 0.15; 95 percent CI 0.64–2.08).

4. Conclusions. The available literature does not allow any conclusions about the relative efficacy of different estrogen inhibitors, although 5 mg of letrozole appears to be superior to 2.5 mg. Pooled data show significantly higher pregnancy rates with gonadotropins compared to estrogen inhibitors, but data are too limited to draw conclusions about live birth rates. There is a trend towards higher rates of multiple pregnancies and OHSS with gonadotropins compared to estrogen inhibitors, but the number of events, even in pooled studies, prevents definite conclusions.

B. Drugs for superovulation - gonadotropins. Given the finding that superovulation with gonadotropins plus IUI results in the highest pregnancy rates along with higher multiple pregnancy rates, the obvious next step is to identify a protocol that optimizes the chances of a live birth while minimizing the multiple gestation risk. This section summarizes studies that address this issue.

1. Identified studies. Identified studies that met our inclusion criteria are summarized in Table 13. Individual studies show no significant difference between urinary and recombinant FSH, although fewer vials are used with rFSH, which may result in reduced treatment costs. Significant differences were not observed between lower and higher dose protocols, although hyper-response, a potential surrogate for OHSS, was higher. Pregnancy rates were consistently higher when GnRH antagonists were used in conjunction with gonadotropins in four studies (significantly in one^109^), while twin rates were 4- to 5-fold higher in three of the four studies.

Table 13 Gonadotropin protocols for superovulation

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Recombinant vs. urinary FSH
Revelli et al., 2006^69^ | Reference | rFSH | 93
Revelli et al., 2006^69^ | | Highly purified urinary FSH | 91 | - | - | - | 0.92 | 0.39 | 2.16
| | | Fewer vials with rFSH, lower cost; cycles/patient: 1.0
Gerli et al., 2004^68^ | Reference | rFSH | 88
Gerli et al., 2004^68^ | | uFSH | 82 | 1.03 | 0.62 | 1.69 | - | - | -
| | | Cycles/patient: 2.23
Demirol and Gurgan, 2007^110^ | Reference | rFSH | 81
Demirol and Gurgan, 2007^110^ | | uFSH | 80 | 0.53 | 0.27 | 1.03 | - | - | -
Demirol and Gurgan, 2007^110^ | | hMG | 80 | 0.48 | 0.24 | 0.96 | - | - | -
| | | Cycles/patient: 1.0
Matorras et al., 2000^111^ | Reference | rFSH | 45
Matorras et al., 2000^111^ | | uFSH | 46 | 0.94 | 0.64 | 1.37 | - | - | -
| | | Cycles/patient: 3.79
FSH vs. hMG
Filicori et al., 2003^112^ | Reference | rFSH | 25
Filicori et al., 2003^112^ | | hMG | 25 | 1.75 | 0.58 | 1.24 | - | - | -
| | | Cycles/patient: 1.0
Gomes et al., 2007^113^ | Reference | rFSH | 17
Gomes et al., 2007^113^ | | hCG | 17 | 2.25 | 0.86 | 5.92 | - | - | -
Gomes et al., 2007^113^ | | hMG | 17 | 1.25 | 0.40 | 3.87 | - | - | -
| | | Cycles/patient: 1.0
Dosing protocols
Leader and Monofollicular Ovulation Induction Study Group, 2006^67^ | Reference | 25 IU | 78
Leader and Monofollicular Ovulation Induction Study Group, 2006^67^ | | 50 IU | 83 | 0.67 | 0.32 | 1.38 | | - | -
| Step-up protocols with different incremental increase if no follicle at least 12 mm by 7 days | | Cycles/patient: 1.0 (dropout rate 27%); ovarian hyper-response 4.26 (1.49, 12.2)
Christin-Maitre, et al., 2003^66^ | Reference | Step down | 39
Christin-Maitre, et al., 2003^66^ | | Step up | 44 | 1.26 | 0.69 | 2.29 | - | - | -
| | | Cycles/patient: 1.9; multiple gestations 0.59 (0.10, 3.35)
Ovulation trigger
Intl. rhCG Study Group, 2001^114^ | Reference | uhCG | 99
Intl. rhCG Study Group, 2001^114^ | | rhCG | 99 | 0.76 | 0.47 | 1.22 | 0.7 | 0.38 | 1.31
| | | Cycles/patient: 1.0
Sakhel et al., 2007^115^ | Reference | uhCG | 144
Sakhel et al., 2007^115^ | | rhCG | 140 | 0.95 | 0.66 | 1.39 | 0.89 | 0.58 | 1.35
| | | Cycles/patient: 1.0
Gondaotropins + GnRH agonists
Karlstrom et al., 2000^116^ | Reference | hMG | 80
Karlstrom et al., 2000^116^ | | hMG + GnRH agonist (buserelin) | 81 | 1.23 | 0.50 | 3.07 | 0.99 | 0.38 | 2.59
| | | Cycles/patient: 1.0; no difference in multiple rates
Gonadotropins + GnRH antagonists
Gomez-Palomares et al., 2005^117^ | Reference | FSH | 42
Gomez-Palomares et al., 2005^117^ | | FSH + GnRH antagonist (cetrorelix) | 40 | 2.63 | 1.13 | 6.09 | - | - | -
| | | Cycles/patient: 1.0
Allegra et al., 2007^109^ | Reference | rFSH only | 52
Allegra et al., 2007^109^ | | rFSH + Cetrorelix | 52 | 1.75 | 1.08 | 2.83 | - | - | -
| | | Cycles/patient: 2.9; twins 4.00 (0.46, 34.6)
Checa et al., 2006^118^ | Reference | rFSH only | 32
Checa et al., 2006^118^ | | rFSH + Cetrorelix | 35 | 1.60 | 0.52 | 4.96 | - | - | -
| | | Cycles/patient: 1.0; twins 5.68 (0.29, 112.1)
Crosignani et al., 2007^119^ | Reference | rFSH only | 151
Crosignani et al., 2007^119^ | | rFSH + Ganirelix | 148 | 0.96 | 0.49 | 1.86 | - | - | -
| | | Cycles/patient: 1.0; twins 5.10 (1.51, 17.3)

2. Other systematic reviews. We did not identify any non-Cochrane published reviews.

3. Cochrane reviews. Results of the relevant Cochrane review,^108^ updated in January 2007, are summarized in Table 14. As has been seen with all of the study reviews, live birth is rarely reported and overall study numbers are small, with no consistent difference in pregnancy rates. Elevated pooled estimates for the risk of multiples and OHSS were observed with higher doses compared to lower doses (multiples 3.11; 95 percent CI 0.48–20.13; OHSS 5.52; 1.85–16.5), and with gonadotropins and GnRH agonists compared to gonadotropins alone (multiples 2.86; 95 percent CI 1.03–7.94; OHSS 2.02; 0.70–5.87). Pooled estimates of multiple pregnancy rates were not elevated with gonadotropins plus GnRH antagonists, but two of the studies noted above which did observe a significant increase in twins were published after this review.

Table 14 Cochrane review, gonadotropins for superovulation^108^

Interventions | | N | Efficacy
Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Relative Effect | Lower 95% CI | Upper 95% CI | Relative Effect | Lower 95% CI | Upper 95% CI
hMG vs. FSH
Reference | FSH | 228
| hMG | 145 | 1.02 | 0.59 | 1.75 | - | - | -
| 5 studies, 4 post-2000
rFSH vs. uFSH
Reference | uFSH | 301
| rFSH | 304 | 1.36 | 0.95 | 1.94 | - | - | -
| 5 studies, all post-2000
Gonadotropins alone vs. gonadotropins + GnRHa
Reference | Gonadotropins | 190
| Gonadotropins + GnRHa | 201 | 0.98 | 0.60 | 1.59 | - | - | -
| 4 studies, 2 post-2000
Gonadotropins alone vs. gonadotropins + GnRH antagonist
Reference | Gonadotropins | 148
| Gonadotropins + GnRH antagonist | 151 | 1.51 | 0.83 | 2.76 | *3.04 | 1.07 | 8.57
| 3 studies, all post-2000 | | *1 study, n = 80
Timing of dosing
Reference | Alternate | 33
| Daily | 30 | - | - | - | 13.71 | 1.62 | 116.3
| 1 study, post-2000
High dose vs. low dose
Reference | Low dose | 149
| High dose | 148 | 1.15 | 0.69 | 1.92 | - | - | -
| 2 studies, 1 post-2000
Ultralong vs. long protocol GnRHa
Reference | Ultra-long | 41
| Long | 39 | 2.59 | 1.02 | 6.59 | - | - | -
| 1 study, pre-2000

4. Conclusions. There do not appear to be substantial differences in pregnancy rates between different gonadotropin preparations. Higher doses increase the risk of multiples and OHSS without significant improvement in pregnancy rates. The addition of GnRH antagonists to superovulation protocols may increase both pregnancy rates and twin gestation rates. Further studies adequately powered for the outcome of live birth per couple are needed.

C. Surgical adjuncts. Surgical procedures to address minor abnormalities detected during the infertility evaluation may result in improved outcomes for those couples who go on to superovulation and IUI.

1. Identified studies. We identified one study^120^ that assessed the utility of diagnosis and treatment of minor abnormalities. Women who were candidates for superovulation and IUI who had small endometrial polyps (mean diameter 16 mm) detected on ultrasound were randomized to hysteroscopy with either biopsy (to rule out malignancy) or resection of the polyps. Polypectomy resulted in significantly higher pregnancy rates (RR 2.23; 95 percent CI 1.57–3.15); data on live birth rates were not presented. Time to pregnancy was substantially shorter in the polypectomy group; of note, 65 percent of the pregnancies in this group occurred before the first IUI.

2. Other systematic reviews. We did not identify any other published or relevant Cochrane reviews.

3. Conclusions. Hysteroscopic resection of ultrasound-detected endometrial polyps results in improved pregnancy rates for women undergoing superovulation and may even obviate the need for further treatment; this would likely result in a decrease in multiple pregnancy rates.

D. Aspects of intrauterine insemination after superovulation. Finally, we reviewed studies that addressed various aspects of IUI after superovulation.

1. Identified studies. We did not identify any studies that met our inclusion criteria.

2. Other systematic reviews. One published systematic review of hCG triggering of ovulation versus urinary LH monitoring for timing of IUI after clomiphene found no significant differences in pregnancy rates in couples with male factor infertility (OR 0.66; 95 percent CI 0.35–1.21) or unexplained fertility (OR 0.79; 0.38–1.64), although hCG triggering did significantly increase rates in anovulatory women, as noted above.

3. Cochrane reviews. In a review updated in July 2007,^121^ three studies published prior to 2000, with a total of 202 subjects, suggest a higher pregnancy rate with IUI compared to timed intercourse with superovulation, but confidence intervals cross 1.0 (OR 1.67; 95 percent CI 0.83–3.37). A review updated in July 2007 found no evidence for superiority of any semen preparation techniques, but the number of subjects was small.^122^ Finally, in a review updated in November 2002,^123^ no differences were observed when comparing single versus double IUI (total number of subjects 355, OR 1.45; 95 percent CI 0.78–2.68).

4. Conclusions. There is insufficient evidence to identify any aspect of IUI that significantly affects pregnancy rates, let alone live birth rates or other less common outcomes.

## Assisted Conception: IVF and ICSI (Question 3)

### I. Research Question

Among women of reproductive age, which laboratory, clinical, and other practice approaches result in the highest successful singleton pregnancy (or live-born) rates, and what practices lead to high multiple rates? Laboratory practices include intracytoplasmic sperm injection (ICSI), different types of embryo culture, fresh versus frozen embryo transfer, and day 2 to 3 versus day 5 to 6 transfer. Clinical practices include number of embryos transferred and selection criteria for eligible patients, as well as using the implantation rates from previous unsuccessful cycles to inform subsequent embryo transfer. Other practices include insurance coverage strategies.

### II. Approach

Some infertile couples are either not candidates for the interventions described in the preceding section (because of tubal disease, for example) or have failed a trial of ovulation induction or superovulation. In all of the interventions described in the previous section, the ovaries are exposed to increased levels of endogenous or exogenous gonadotropins, and may or may not receive additional agents to trigger ovulation (the extrusion of the egg[s] from the ovary), but the individual steps of ovulation, exposure to sperm, fertilization, and initial development of the embryo all take place within the patient's body. The interventions described in this section involve direct intervention with at least one, and most commonly all, of these individual steps.

The review is organized around interventions applied to the individual steps in the process, based on the most commonly used protocols. Interventions are divided into those used in the female partner, in the male partner, and in the embryo.

For the female partner, interventions include:

a) Suppression of endogenous pituitary gonadotropin secretion (pituitary down-regulation);
b) Stimulation of follicular development with exogenous agents (controlled ovarian hyperstimulation);
c) Triggering of ovulation;
d) Retrieval of oocytes;
e) Replacement of gametes (relevant only for gamete intrafallopian transfer [GIFT]);
f) Transfer of the embryo;
g) Luteal support;
h) Other adjunctive therapies; and
i) Strategies for prevention of ovarian hyperstimulation syndrome (OHSS).

For the male partner, interventions include:

a) Methods for sperm retrieval; and
b) Methods for sperm preparation.

For the embryo, interventions include:

a) Methods for fertilization;
b) Methods to support early embryonic growth;
c) Methods for preparation for transfer;
d) Methods for embryo storage for future transfers;
e) Selection of embryos for transfer;
f) Timing of embryo transfer;
g) Number of embryos to transfer.

Our focus here is on interventions that can feasibly be evaluated using randomized trials; as mentioned in the Introduction, there was almost no literature on the male partner, so this section focuses on interventions focusing on the female partner and the embryo. The effect of broader interventions, such as insurance coverage for specific procedures, is more difficult to evaluate. Although there are some data on the effects of varying insurance policies on outcomes, the evaluation of the effectiveness of these policies involves completely different methods. The available data, and their implications for clinical care and policy, are discussed in the final chapter of this report.

Our general approach to study inclusion and summarization was similar to the one used for studies of ovulation induction and superovulation. As described in the Methods chapter, we excluded all non-randomized studies, as well as “quasi-randomized” studies (such as those where treatment assignment was based on alternate history numbers or clinic days). For this topic, the primary outcome of interest was the cumulative number of clinical pregnancies or, preferably, live births per couple; wherever possible, we used the number of women/couples randomized as the denominator. We excluded any study where these outcomes were not reported or calculable from the presented results.

For the primary outcomes, relative risks (RRs) with 95 percent CIs were calculated from the presented results. Because of substantial clinical heterogeneity in the studies in terms of patient characteristics (such as BMI in studies of PCOS) and treatment regimens, we did not perform formal meta-analyses.

Results for other outcomes, such as multiple pregnancy or spontaneous abortion rates, are summarized in the text. The majority of included studies were extremely limited in power to detect differences in the primary outcomes, let alone any differences in other less common outcomes. Outcomes related to later pregnancy and longer term maternal and child outcomes are discussed under Question 4.

### III. Search Results

The flow of articles on this topic through the literature search and screening process is depicted in Figure 4.

Figure 4. Literature flow diagram - Question 3

### IV. The Female Partner

Up to and including embryo transfer, the overall immediate short-term goal of each step in the IVF process is to maximize the probability of success at the next step, with the ultimate goal of maximizing the likelihood of a healthy live birth. This is usually achieved by maximizing the number of “units” available for the subsequent step. Thus, controlled ovarian hyperstimulation aims at maximizing the number of follicles suitable for oocyte retrieval, where as many eggs as possible are retrieved, after which as many embryos as possible are cultured. All other things being equal, increasing the number of embryos improves the likelihood that at least one will develop and progress to a live birth.

Unfortunately, this “maximization” strategy increases the risk of multiple pregnancies, as well as the risk of OHSS. As a rule, the ultimate goal for comparative trials of these steps is to identify interventions that maximize the chances of a healthy live birth while minimizing the risks of multiple pregnancy and complications such as OHSS.

A. Methods for pituitary down-regulation. In the normal menstrual cycle, ovulation is triggered by a surge of luteinizing hormone (LH) in response to feedback mechanisms involving ovarian hormones at the level of the hypothalamus and pituitary. Hyperstimulation of the ovaries with exogenous gonadotropins in women with a normal hypothalamic/pituitary/ovarian axis alters these feedback mechanisms and, potentially, the timing of the LH surge. Since the goal of hyperstimulation in the setting of IVF is to have as many eggs as possible to retrieve through the development of as many follicles as possible, a premature spontaneous LH surge may lead to ovulation prior to retrieval, forcing the cancellation of the entire IVF cycle.^124^

Two general approaches have been used. The “classic” technique involves the use of a gonadotropin-releasing hormone (GnRH) agonist, given beginning 2 to 3 weeks before the IVF cycle. More recently, direct antagonists of the GnRH receptor, which do not require pre-treatment, have been introduced.

1. Included studies. We identified nine studies comparing different aspects of GnRH agonist administration that met our inclusion criteria (Table 15). In general, none of the comparisons of timing, dose, or type of agonist showed significant improvements in pregnancy or, when reported, live birth rates. The one exception was a comparison of a reduced dose of triptorelin compared to the standard dose, which showed significant improvement in both cycle-specific pregnancy rates and cumulative rates when using subsequent frozen embryo transfer.^125^

Table 15 Methods for pituitary down-regulation - GnRH agonists alone^†^

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
GnRH agonist: dosing/timing/type
Dal Prato et al., 2004^125^ | Reference | 3.50 mg triptorelin | 90
Dal Prato et al., 2004^125^ | | 1.87 mg triptorelin | 90 | 1.65 | 1.03 | 2.65 | - | - | -
| | | Cumulative pregnancy rate with frozen transfer 1.69 (1.19, 2.41) ; intent-to-treat outcomes better than reported results
Yim et al., 2001^126^ | Reference | 3.50 mg triptorelin | 30
| 1.87 mg triptorelin | 30 | 0.67 | 0.27 | 1.64 | - | - | -
Dal Prato et al., 2001^127^ | Reference | Depot triptorelin (3.50 mg) | 66
| Daily triptorelin (100 ug until menses, then 50 ug) | 66 | 0.92 | 0.57 | 1.46 | - | - | -
Fabregues et al., 2005^128^ | Reference | 0.1 mg triptorelin daily | 68
| 0.1 mg triptorelin daily, then 0.5 mg | 69 | 1.02 | 0.68 | 1.54 | - | - | -
Garcia-Velasco et al., 2000^129^ | Reference | Long protocol (leuprolide) | 34
| Stop protocol (stop with onset menses) | 36 | 0.79 | 0.26 | 2.34 | - | - | -
Simons et al., 2005^130^ | Reference | Long protocol | 58
Simons et al., 2005^130^ | | Short protocol (triptorelin) (stop on day of gonadotropin start) | 58 | 1.31 | 0.70 | 2.44 | 1.33 | 0.69 | 2.56
| Medium protocol (triptorelin) (stop day 4 gonadotropins) | 62 | 1.41 | 0.78 | 2.57 | 1.17 | 0.60 | 2.28
Orvieto et al., 2002^131^ | Reference | Depot agonist (leuprolide) | 26
| Depot agonist (triptorelin) | 26 | 0.42 | 0.17 | 1.02 | - | - | -
Dor et al., 2000^132^ | Reference | hMG only | 26
Dor et al., 2000^132^ | | Intranasal GnRH agonist (buserelin) | 24 | 1.30 | 0.46 | 3.71 | - | - | -
| IM GnRH agonist (triptorelin) | 24 | 1.52 | 0.56 | 4.14 | - | - | -
Isikoglu et al., 2007^133^ | Reference | GnRH agonist stop with hCG administration | 91
| GnRH agonist through day 12 post-transfer | 90 | 0.99 | 0.74 | 1.33 | 1.07 | 0.73 | 1.58

† All studies had 1.0 cycles/patient unless otherwise noted.

We identified 14 studies directly comparing GnRH agonists and antagonists (Table 16). Pregnancy rates did not differ significantly in any of the individual studies, although none were adequately powered or designed as equivalency studies. In studies where relative OHSS rates were calculable, rates were consistently lower with antagonists, although this was statistically significant in only one.^134^

Table 16 Methods for pituitary down-regulation - GnRH agonists versus antagonists^†^

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
GnRH agonists vs GnRH antagonists
Albano et al., 2000^135^ and Ludwig et al., 2000^134^ (OHSS results) | Reference | Agonist (buserelin) | 88
Albano et al., 2000^135^ and Ludwig et al., 2000^134^ (OHSS results) | | Antagonist (ganirelix) | 188 | 0.89 | 0.57 | 1.40 | 0.84 | 0.51 | 1.38
| | | Multiples (twins) 2.10 (0.49, 1.38); OHSS 0.18 (0.04, 0.91)
Bahceci et al., 2005^136^ | Reference | Agonist (leuprolide) | 59
Bahceci et al., 2005^136^ | | Antagonist (cetrorelix) | 70 | 1.02 | 0.76 | 1.36 | - | - | -
| | | Equivalent multiples
Barmat et al., 2005^137^ | Reference | Agonist (leuprolide) | 41
| Antagonist (ganirelix) | 38 | 0.82 | 0.47 | 1.41 | 0.76 | 0.42 | 1.38
Check et al., 2004^138^ | Reference | Agonist (leuprolide) | 28
| Antagonist (ganirelix) | 19 | 0.74 | 0.34 | 1.62 | 0.98 | 0.42 | 2.31
European and Middle East Orgalutran Study Group, 2001^139^ | Reference | Agonist (triptorelin) | 111
European and Middle East Orgalutran Study Group, 2001^139^ | | Antagonist (ganirelix) | 226 | 0.93 | 0.67 | 1.29 | - | - | -
| | | Multiples not reported; OHSS 0.12 (0.01, 1.09)
Hohmann et al., 2003^140^ | Reference | Agonist (triptorelin) long protocol | 45
Hohmann et al., 2003^140^ | | Antagonist (cetrorelix) day 2 | 48 | 0.94 | 0.43 | 2.04 | - | - | -
| Antagonist (cetrorelix) day 5 | 49 | 0.92 | 0.42 | 2.00 | - | - | -
Lee et al., 2005^141^ | Reference | Agonist (buserelin) | 20
Lee et al., 2005^141^ | | Daily antagonist (cetrorelix) beginning day 5 | 20 | 1.11 | 0.58 | 2.14 | - | - | -
| Single dose antagonist (cetrorelix) day 7 | 20 | 0.56 | 0.23 | 1.37 | - | - | -
Olivennes et al., 2000^142^ | Reference | Agonist (triptorelin) | 39
| Antagonist (cetrorelix) | 115 | 0.80 | 0.44 | 1.47 | - | - | -
Sauer et al., 2004^143^ | Reference | Agonist (leuprolide) | 25
Sauer et al., 2004^143^
| Antagonist (cetrorelix) | 25 | 1.00 | 0.54 | 1.87 | - | - | -
| Antagonist + midcycle rLH | 24 | 0.95 | 0.50 | 1.81 | - | - | -
Vlaisavljevic et al., 2003^144^ | Reference | Agonist (goserelin) | 226
Vlaisavljevic et al., 2003^144^
| Antagonist (cetrorelix) | 236 | 1.08 | 0.83 | 1.40 | 1.06 | 0.80 | 1.41
| | | Multiples 0.66 (0.33, 1.33); severe OHSS 0.55 (0.16, 1.84)
Borme and Mannaerts, 2000^145^ | Reference | Agonist (buserelin) | 238
Borme and Mannaerts, 2000^145^
| Antagonist (ganirelix) | 463 | 0.76 | 0.59 | 0.99 | 0.81 | 0.61 | 1.07
| | | Multiples 0.69 (0.38, 1.24) ; OHSS 0.65 (0.30, 1.65)
Loutradis et al., 2004^146^ | Reference | Agonist (triptorelin) | 58
| Antagonist (cetrorelix) | 58 | 0.79 | 0.39 | 1.58 | - | - | -
Zikopoulos et al., 2005^147^ | Reference | Agonist (buserelin) | 29
Zikopoulos et al., 2005^147^
| Antagonist (cetrorelix) | 36 | 0.99 | 0.58 | 1.71 | 0.72 | 0.29 | 1.81
| | | Multiples 1.21 (0.38, 3.88)
Fluker et al., 2001^148^ | Reference | Agonist (leuprolide) | 105
Fluker et al., 2001^148^ | | Antagonist (ganirelix) | 208 | 0.93 | 0.68 | 1.28 | 0.86 | 0.61 | 1.20
| | | OHSS 3.03 (0.69, 13.2)

† All studies had 1.0 cycles/patient unless otherwise noted.

We identified one other randomized trial comparing a GnRH long agonist protocol to a protocol of pre-treatment with oral contraceptives, clomiphene citrate plus rFSH, and rLH plus prednisolone in 194 subjects;^149^ pregnancy rates were not significantly different (RR 1.20; 95% CI 0.86–1.67), and OHSS rates were lower with the clomiphene-based regimen (RR 0.23; 0.07–0.79). We did not find any additional studies evaluating this regimen.

Studies that compared different dosing, timing, or types of GnRH antagonists did not show significant differences in pregnancy rates (Table 17). However, three studies of pre-treatment with oral contraceptives (in order to allow scheduling of the beginning of the stimulation cycle) followed by an antagonist suggest, at best, no benefit and possibly worse outcomes with this regimen. Oral contraceptives followed by an antagonist had similar pregnancy rates compared with long protocol GnRH agonist in a small study of PCOS patients who had previously failed clomiphene,^150^ and non-significantly lower rates in a larger trial (which excluded PCOS subjects).^151^ In the Rombauts study^151^ and two others comparing the addition of pre-treatment with OCPs to GnRH antagonists alone,^152,153^ pregnancy rates were lower, significantly so in one.^152^

Table 17 Methods for pituitary down-regulation - GnRH antagonist regimens

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
GnRH antagonists: dosing/timing /type
Wilcox et al., 2005^154^ | Reference | Cetrorelix | 87
| Ganirelix | 88 | 0.94 | 0.67 | 1.31 | - | - | -
Escudero et al., 2004^155^ | Reference | GnRH antagonist when lead follicle > 14 mm | 51
| GnRH antagonist on day 6 after gonadotropins | 45 | 1.15 | 0.75 | 1.75 | - | - | -
Mochtar and the Dutch Banirelix Study Group, 2004^156^ | Reference | GnRH antagonist when lead follicle > 14 mm | 101
| GnRH antagonist on day 6 after gonadotropins | 103 | 1.45 | 0.92 | 2.28 | 1.43 | 0.89 | 2.28
GnRH antagonist + OCPs
Hwang et al., 2004^150^ | Reference | Long agonist (buserelin) | 29
PCOS patients | OCP pre-treatment + antagonist (ganirelix) | 27 | 1.07 | 0.53 | 2.17 | - | - | -
Huirne et al., 2006^152^ | | Gonadotropin + antagonist (Antide) | 32
| OCP pre-treatment + antagonist (antid) | 32 | 0.34 | 0.12 | 0.95 | 0.52 | 0.17 | 1.54
Kolibianakis et al., 2006^153^ | Reference | Gonadotropin + antagonist (ganirelix) | 250
Kolibianakis et al., 2006^153^ | | OCPs cycle prior to COH + Gonadotropin + antagonist | 254 | - | - | - | 0.86 | 0.62 | 1.20
| | | Pregnancy loss 1.73 (0.92, 3.29)
Rombauts et al., 2006^151^ | Reference | Agonist (naferelin) | 111
Rombauts et al., 2006^151^ | | Antagonist (ganirelix) | 110 | - | - | - | 0.89 | 0.54 | 1.46
| OCP + ganirelix | 111 | - | - | - | 0.69 | 0.40 | 1.19

We identified six studies in patients with either a history of a poor response to standard hyperstimulation protocols,^157^–^159^ a low likelihood of a good response based on age or basal FSH levels,^160,161^ or endometriosis^162^(Table 18). The five studies comparing antagonists to agonists did not show significant differences or a consistent pattern of one type of agent being superior to the other. In the one study comparing two GnRH agonist protocols, a short protocol was significantly inferior to a long protocol.

Table 18 Down-regulation protocols in patients at risk of poor response

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
History of poor response
Cheung et al., 2005^157^ | Reference | Agonist (buserelin) | 32
Cheung et al., 2005^157^ | | Antagonist (cetrorelix) | 31 | 1.72 | 0.45 | 6.59 | - | - | -
| Poor responders
Malmusi et al., 2005^158^ | Reference | Agonist (triptorelin) flare | 30
Malmusi et al., 2005^158^ | | Antagonist (ganirelix) | 25 | 0.60 | 0.17 | 2.16 | - | - | -
| Poor responders
Marci et al., 2005^159^ | Reference | Agonist (leuprolide) | 30
Marci et al., 2005^159^ | | Antagonist (cetrorelix) | 30 | 2.50 | 0.53 | 11.89 | 8.00 | 0.44 | 144.8
| Poor responders
Likely to have poor response
De Placido et al., 2006^160^ | Reference | Agonist (triptorelin) +LH | 66
De Placido et al., 2006^160^ | | Antagonist (ganirelix) | 67 | 0.81 | 0.44 | 1.51 | - | - | -
| High risk for poor response based on age or basal FSH
Sbracia et al., 2005^161^ | Reference | Long protocol (buserelin) | 110
Sbracia et al., 2005^161^ | | Short protocol (buserelin) | 110 | 0.48 | 0.25 | 0.91 | - | - | -
| Age ≥ 40
Endometriosis
Pabuccu et al., 2007^162^ | Reference | Agonist (triptorelin) | 122
Pabuccu et al., 2007^162^ | | Antagonist (cetrorelix) | 124 | 0.83 | 0.56 | 1.23 | - | - | -
| | | Results similar for different subgroups (Stage I–II, resected endometrioma, active endometrioma)

2. Other systematic reviews. We did not identify any relevant non-Cochrane reviews.

3. Cochrane reviews. There are three relevant Cochrane reviews, which are summarized in Table 19. The first, updated in September 2004, focuses on comparisons of a long-acting depot form of a GnRH agonist to daily administration.^163^ No significant differences in pregnancy or live birth rate were found, although the gonadotropin requirement was lower with daily administration.

Table 19 Cochrane reviews, pituitary down-regulation

Interventions | | N | Efficacy
Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Relative Effect | Lower 95% CI | Upper 95% CI | Relative Effect | Lower 95% CI | Upper 95% CI
GnRH agonist - daily vs. depot^163^
Reference | Daily | 289
| Depot | 263 | 0.94 | 0.65 | 1.37 | 0.85 | 0.54 | 1.36
| 6 studies, 1 post-2000 | | | | | 4 studies, 1 post-2000, n = 392
GnRH agonists vs. antagonists^124^
Reference | GnRH agonist | 1804
| GnRH antagonist | 2554 | 0.83 | 0.72 | 0.95 | 0.82 | 0.68 | 0.97
| | | | | | 15 studies, all post-2000, n = 2973
Poor responders^164^
GnRH agonist - long vs. stop protocol
Reference | Stop protocol | 74
| Long protocol | 74 | 0.86 | 0.31 | 2.37 | 0.51 | 0.04 | 5.91
| 2 studies, 1 post-2000, outcomes per cycle | | | | | 1study, pre-2000, n = 78, ongoing pregnancy/cycle
GnRH agonist vs. antagonist
Reference | Long protocol | 30
| Antagonist | 30 | 2.80 | 0.50 | 15.7 | - | - | -
| 1 study, post-2000 | | Significantly fewer units gonadotropin required with antagonist
GnRH agonist vs. bromocrytine
Reference | Long protocol | 31 | 5.60 | 1.40 | 22.5 | 3.65 | 0.88 | 15.1
| Bromocrytine | 32 | 5.60 | 1.40 | 22.5 | 3.65 | 0.88 | 15.1
| 1 study, pre-2000

The second review^124^ performed a meta-analysis of studies comparing GnRH agonists to antagonists. Pooled data showed a significant reduction in both pregnancy (OR 0.83; 95 percent CI 0.72–0.95) and live birth (OR 0.82; 0.68–0.97), multiple pregnancy rates were not significantly different (OR 0.82; 0.57–1.18). Antagonists significantly lowered the risk of severe OHSS (OR 0.61; 0.42–0.89), as well as the dosage and duration of gonadotropin required.

Finally, a review of interventions for poor responders^164^ did not find sufficient evidence to draw conclusions about efficacy for any of the regimens reviewed.

4. Conclusions. Only a few of the studies we identified had adequate power to detect differences in pregnancy or live birth rates, let alone less common outcomes such as multiple pregnancy or OHSS. We did not identify clear evidence of the superiority of any specific protocol involving GnRH agonists. In the setting of endometrial preparation for frozen-thawed embryo transfer, two relatively large studies had conflicting results regarding the benefit of adding an agonist; further research is needed.

Although only one individual study comparing GnRH agonists to antagonists found a significant difference in pregnancy or live birth rates (in favor of agonists), formal meta-analysis shows a significantly lower pregnancy and live birth rate with the use of antagonists; antagonists do result in significant decreases in gonadotropin requirements, and a significant decrease in the risk of OHSS.

Pre-treatment with an oral contraceptive to assist with scheduling GnRH antagonist cycles resulted in decreases in pregnancy rates in all three identified studies; this reduction was statistically significant in one.

Finally, although there is no clear evidence for superiority of any strategy for improving outcomes in patients with a history of poor response, a long GnRH agonist protocol was superior to a short GnRH protocol in women over 40 in one trial.

B. Methods for ovarian stimulation. Once endogenous gonadotropin down-regulation has occurred, exogenous gonadotropins need to be administered in order to stimulate follicular development. A variety of preparations are available. The classic method uses human menopausal gonadotropin (hMG), which contains both LH and FSH; in addition to hMG, pure FSH, derived either from urine (uFSH) or as a recombinant form (rFSH), is also available. All three of these can stimulate follicular development alone. Because LH is part of normal follicular development in ovulating women, adding recombinant LH (rLH) to protocols using rFSH theoretically may improve outcomes.^165^ In addition, some women do not produce multiple follicles (usually defined as three or more) in response to standard stimulation protocols and are classified as “poor responders;” women who are above age 35, or who have elevated levels of FSH early in a spontaneous cycle, are at increased risk of poor response.^164^

1. Included studies. We identified 38 studies meeting inclusion criteria. Results are summarized in tables for comparisons of rFSH versus hMG, rFSH versus uFSH, and different rFSH preparations (Table 20); rFSH alone versus rFSH plus rLH (Table 21); various gonadotropin dosing regimens (Table 22); methods of administering gonadotropins (Table 23); and protocols for stimulation in poor responders (Table 24). Of all the studies, only two individual studies showed a significant improvement in pregnancy rates: individualized dosing protocol based on a nomogram was superior to a fixed dose regimen,^166^ and a regimen of urinary FSH for 6 days followed by rFSH was superior to FSH alone.^167^ Only one study^168^ was explicitly designed as an equivalence trial. From both a statistical and regulatory perspective, demonstrating equivalence or non-inferiority requires specific a priori hypotheses about the degree of difference in efficacy, and in general requires a larger sample size than studies designed to demonstrate superiority.^36^ This means that, in spite of a lack of demonstrable superiority of one preparation or another, it is not possible to conclude that the preparations are in fact equivalent in efficacy.

Table 20 Ovarian stimulation - different gonadotropin preparations

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Single gonadotropin: rFSH vs. HMG
Andersen et al., 2006^169^ | Reference | rFSH | 368
| hMG | 363 | 1.20 | 0.93 | 1.55 | 1.19 | 0.92 | 1.53
European and Israeli Study Group, 2002^168^ | Reference | rFSH | 354
European and Israeli Study Group, 2002^168^ | | Highly purified hMG | 373 | 1.19 | 0.92 | 1.55 | 1.13 | 0.86 | 1.49
| | | Multiple gestation 0.89 (0.58, 1.36)
Westergaard et al., 2001^170^ | Reference | Subcutaneous agonist + rFSH | 92
Westergaard et al., 2001^170^ | GnRH agonist: buserelin | Subcutaneous agonist +hMG | 89 | - | - | - | 1.16 | 0.74 | 1.82
Westergaard et al., 2001^170^ | | Intranasal agonist + hMG | 100 | - | - | - | 1.44 | 0.95 | 2.17
| Intranasal agonist + rFSH | 98 | - | - | - | 1.05 | 0.66 | 1.66
Gordon et al., 2001^171^ | Reference | rSH (0 LH) | 39
Gordon et al., 2001^171^ | | uFSH (0.1 IU LH) | 30 | 0.47 | 0.17 | 1.34 | 0.24 | 0.06 | 0.99
Gordon et al., 2001^171^ | | hMG 25 IU LH | 30 | 0.95 | 0.43 | 2.06 | 0.71 | 0.30 | 1.70
| hMG 75 IU LH | 29 | 1.34 | 0.68 | 2.66 | 1.10 | 0.53 | 2.30
Ng et al., 2001^172^ | Reference | rFSH | 20
Ng et al., 2001^172^ | | hMG | 20 | 1.25 | 0.39 | 3.99 | - | - | -
| | | Multiples 1.34 (0.62, 1.89)
Strehler et al., 2001^173^ | Reference | rFSH | 296
| hMG | 282 | 1.08 | 0.83 | 1.40 | - | - | -
Dickey et al., 2003^174^ | Reference | Follitropin-β | 118
| Highly purified FSH | 120 | 1.11 | 082 | 1.52 | 1.09 | 0.76 | 1.55
Kilani et al., 2003^175^ | Reference | rFSH | 50
| Highly purified hMG | 50 | 0.93 | 0.51 | 1.72 | 0.92 | 0.45 | 1.88
rFSH vs. urinary FSH
Schats et al., 2000^176^ | Reference | rFSH | 247
| Highly purified urinary FSH | 249 | 0.76 | 0.53 | 1.09 | - | - | -
Selman et al., 2002^177^ | Reference | rFSH
| Highly purified urinary FSH | | 1.26 | 0.95 | 1.69 | 1.29 | 0.93 | 1.79
Frydman et al., 2000^178^ | Reference | rFSH | 139
Frydman et al., 2000^178^ | | Urinary FSH | 139 | 1.00 | 0.61 | 1.65 | 0.97 | 0.65 | 1.45
| | | OHSS 0.43 (0.11, 1.62)
Mohamed et al., 2006^179^ | Reference | rFSH | 128
| uFSH | 129 | - | - | - | 1.09 | 0.63 | 1.86
Pacchiarotti et al., 2007^167^ | Reference | rFSH only | 61
| uFSH for 6 days, followed by rFSH | 58 | 2.02 | 1.15 | 3.56 | - | - | -
Different recombinant FSHs
Moon et al., 2007^180^ | Reference | rFSH (follitropin | 48
| DA-3801 | 49 | 0.73 | 0.34 | 1.58 | 0.80 | 0.37 | 1.76

Table 21 Ovarian stimulation - rFSH alone versus rFSH + rLH

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
FSH vs. FSH + LH
Humaidan et al., 2004^181^ | Reference | rFSH | 115
| rFSH + rLH | 116 | 1.19 | 0.82 | 1.72 | - | - | -
Marrs et al., 2004^182^ | Reference | rFSH | 219
| rFSH + rLH | 212 | 1.02 | 0.82 | 1.28 | - | - | -
Tarlatzis et al., 2006^183^ | Reference | rFSH | 59
| rFSH +rLH | 55 | 0.69 | 0.32 | 1.46 | 0.64 | 0.25 | 1.65
Koicihi et al., 2006^184^ | Reference | GnRH agonist + uFSH | 66
Koicihi et al., 2006^184^ | | GnRH antagonist + uFSH | 63 | 0.67 | 0.44 | 1.02 | - | - | -
| GnRH antagonist + uFSH + hCG | 63 | 0.73 | 0.49 | 1.10 | - | - | -
Griesinger et al., 2005^185^ | Reference | rFSH | 65
GnRH antagonist | rFSH + rLH | 62 | 0.70 | 0.31 | 1.59 | - | - | -
Levi-Setti et al., 2006^186^ | Reference | rFSH | 20
Levi-Setti et al., 2006^186^ | | rFSH + rLH | 20 | 1.17 | 0.48 | 2.86 | - | - | -
| Antagonist
Serafini et al., 2006^187^ | Reference | GnRH agonist + uFSH | 98
Serafini et al., 2006^187^ | | GnRH antagonist + uFSH | 96 | 0.93 | 0.67 | 1.30 | - | - | -
| GnRH antagonist + uFSH + hCG | 103 | 1.25 | 0.94 | 1.66 | - | - | -
Drakakis et al., 2005^188^ | Reference | rFSH | 22
Drakakis et al., 2005^188^ | | rFSH + hMG | 24 | 0.76 | 0.27 | 2.15 | - | - | -
| 1^st^ 4 days of stimulation
Balasch et al., 2001^189^ | Reference | rFSH | 14
| rFSH +LH | 16 | 0.21 | 0.01 | 4.33 | - | - | -

Table 22 Ovarian stimulation - gonadotropin dosing regimens

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Aboulghar et al., 2004^190^ | Reference | Standard dose gonadotropins | 72
Aboulghar et al., 2004^190^ | | ↑ by 75 IU from time of GnRH antagonist | 79 | 1.15 | 0.74 | 1.79 | - | - | -
| GnRH antagonist | | Multiples 0.97 (0.49, 1.93)
Klinkert et al., 2005^191^ | Reference | 150 IU rFSH | 26
Klinkert et al., 2005^191^ | | 300 IU rFSH | 26 | 0.30 | 0.04 | 3.00 | 0.50 | 0.05 | 5.18
| Low antral follicle count
Out et al., 2004^192^ | Reference | 150 IU rFSH | 132
| 200 IU rFSH | 132 | - | - | - | 0.78 | 0.53 | 1.16
Popovic-Todorovic et al., 2003^166^ | Reference | Standard step-up FSH | 131
| Individualized dose based on nomogram | 131 | 1.50 | 1.03 | 2.18 | - | - | -
Hoomans et al., 2002^193^ and Ng et al., 2000^194^ | Reference | 200 IU rFSH | 166
| 100 IU rFSH | 163 | 1.12 | 0.72 | 1.75 | 1.10 | 0.67 | 1.81
Latin-American Puregon IVF Study Group, 2001^195^ | Reference | 150 IU rFSH | 201
| 250 IU rFSH | 203 | 0.99 | 0.64 | 1.53 | - | - | -
Hugues et al., 2003^196^ | Reference | rFSH dose prepared by bioassay | 65
| rFSH dose prepared by mass | 66 | 1.16 | 0.67 | 2.01 | - | - | -
Propst et al., 2006^197^ | Reference | Constant dose rFSH | 30
| Step-up protocol | 30 | 0.86 | 0.59 | 1.25 | 1.06 | 0.69 | 1.62
Scholtes et al., 2004^198^ | Reference | 150 IU rFSH daily | 51
| 450 IU rFSH every 3 days | 51 | 1.86 | 0.81 | 4.27 | 0.83 | 0.27 | 2.56

Table 23 Ovarian stimulation - methods of administering gonadotropins

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Greco et al., 2005^199^ | Reference | rFSH via syringe | 152
| rFSH via injector | 148 | 1.17 | 0.89 | 1.53 | - | - | -
Platteau et al., 2003^200^ | Reference | rFSH via syringe | 104
| rFSH via injector | 96 | 1.02 | 0.70 | 1.49 | 0.99 | 0.66 | 1.47

Table 24 Protocols for stimulation in poor responders

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Gomez-Palomares et al., 2005^201^ | Reference | rFSH + rLH 1^st^ 5 days stimulation | 36
Gomez-Palomares et al., 2005^201^ | | rFSH + hMG 1^st^ 5 days stimulation | 58 | 0.47 | 0.25 | 0.87 | - | - | -
| Women > 38 years
De Placido et al., 2005^202^ | Reference | rFSH step-up | 65
De Placido et al., 2005^202^ | | rFSH + rLH | 65 | 1.46 | 0.79 | 2.71 | - | - | -
| Poor responders
De Placido et al., 2001^203^ | Reference | rFSH step-up | 23
De Placido et al., 2001^203^ | | hMG | 20 | 1.44 | 0.71 | 2.93 | - | - | -
| Initial poor ovarian response
Fabregues et al., 2006^204^ | Reference | rFSH | 60
| rFSH + LH | 60 | 1.04 | 0.68 | 1.60 | - | - | -

2. Other systematic reviews. We did not identify any relevant non-Cochrane reviews.

3. Cochrane reviews. There are two relevant Cochrane reviews^165,205^(Table 25). In the review of hMG versus rFSH, last updated in August 2002,^205^ hMG was significantly superior to rFSH in terms of pregnancy rates (OR 1.28; 95 percent CI 1.11–1.54), and nearly so for live birth rates (OR 1.27; 0.98–1.64). hMG required significantly more medication, however, and the rate of multiple gestations was higher (OR 1.48; 0.98–2.16). In the review of rFSH versus rFSH plus rLH,^165^ the addition of rLH to rFSH significantly increased live birth rates in previous poor responders (OR 1.85; 95 percent CI 1.10–3.11).

Table 25 Cochrane reviews, ovarian stimulation

Interventions | | N | Efficacy
Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Relative Effect | Lower 95% CI | Upper 95% CI | Relative Effect | Lower 95% CI | Upper 95% CI
hMG vs. rFSH^205^
No down-regulation
Reference | rFSH | 54
| hMG | 35 | 0.94 | 0.35 | 2.53 | 0.73 | 0.26 | 8.20
| 1 study, pre-2000
Short protocol GnRH agonist
Reference | rFSH | 296
| hMG | 288 | 1.11 | 0.77 | 1.60 | - | - | -
| 1 study, post-2000
Long protocol GnRH agonist
Reference | rFSH | 603
| hMG | 611 | 1.28 | 1.11 | 1.54 | 1.27 | 0.98 | 1.64
| 4 studies, all post-2000 | | Multiples 1.48 (0.98–2.16), significant increase in gonadotropin dose with hMG
rLH + rFSH vs. rFSH alone^165^
rLH + rFSH vs. rFSH alone, GnRH agonist down-regulation
Reference | rFSH only | 630
| rFSH + rLH | 626 | 1.15 | 0.91 | 1.45 | 1.51 | 0.79 | 2.87
| 7 studies, all post-2000 | | | | | 2 studies, n = 22;
rLH + rFSH vs. rFSH alone, GnRH antagonist down-regulation
Reference | rFSH only | 24
| rFSH + rLH | 25 | 0.79 | 0.26 | 2.43 | 0.83 | 0.39 | 1.80
| | | | | | 2 studies, both post-2000, n = 166
rLH + rFSH vs. rFSH alone, GnRH agonist down-regulation, poor responders
Reference | rFSH only | 155
| rFSH + rLH | 155 | - | - | - | 1.85 | 1.10 | 3.11
| 3 studies

4. Conclusions. Trials of methods for ovarian stimulation in the setting of IVF, like those of methods for pituitary down-regulation, are consistently underpowered to detect differences in pregnancy rates or live birth rates, and few are specifically designed to demonstrate equivalence in these outcomes. Power to detect less common outcomes such as multiple pregnancy or OHSS is even lower. There is evidence from one trial that pregnancy rates are superior with an individualized dosing regimen of rFSH compared to fixed dosing. Pooled results of individual trials suggest that hMG is superior to rFSH in long protocol GnRH agonist regimens, with higher multiple pregnancy rates, and that the addition of rLH to rFSH improves live birth rates in poor responders.

C. Methods for follicular maturation. In a spontaneous ovulatory cycle, final maturation and rupture of the follicle, resulting in release of the ovum, is triggered by a surge in LH; this surge also promotes luteinization, resulting in production of the progesterone necessary for endometrial preparation for implantation and early placentation.^206^ In controlled hyperstimulation, although ovum release is not needed (or desirable), human chorionic gonadotropin (hCG), which has biological activity similar to LH, has traditionally been given to induce final maturation prior to oocyte retrieval. Recent developments that might theoretically improve outcomes are the development of recombinant hCG (rhCG), which would provide a purer, more consistent product than urinary LH (uLH), and recombinant LH (rLH), which, because of a shorter duration of action, might reduce the risk of OHSS. An alternative approach in patients treated with a short-acting GnRH antagonist could be induction of an endogenous LH surge through administration of a GnRH agonist.

1. Included studies. Studies meeting inclusion criteria are shown in Table 26. One study evaluated two different protocols for timing of administration of hCG.^207^ Under ultrasound monitoring beginning on day 6 of stimulation, subjects were randomized to administration of hCG as soon as at least three follicles had reached at least 17 mm in diameter, or 2 days after this point. Live birth rates were significantly lower in the late hCG group (RR 0.72; 95 percent CI 0.53–0.98); including biochemical pregnancies and miscarriages, early pregnancy loss was two-fold greater in the late hCG group.

Table 26 Methods for inducing final follicular maturation

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
hCG timing
Kolibianakis et al., 2004^207^ | Reference | hCG when at least 3 follicles at least 17 mm | 208
Kolibianakis et al., 2004^207^ | | hCG 2 days later | 205 | 0.87 | 0.68 | 1.13 | 0.72 | 0.53 | 0.98
| Down-regulation with antagonist | | Cycles/patient 1.0; multiples 0.52 (0.24, 1.14); higher early loss rate with late hCG
uhCG vs. rhCG
Euorpean rhCG Study Group, 2000^208^ | Reference | uhCG | 93
Euorpean rhCG Study Group, 2000^208^ | | rhCG | 97 | 1.50 | 0.80 | 2.82 | 1.26 | 0.65 | 2.43
| | | Multiples 0.95 (0.36, 2.52); OHSS 1.13 (0.36, 3.49)
Driscoll et al., 2000^209^ | Reference | uhCG | 40
| rhCG | 44 | 0.89 | 0.26 | 3.04 | 1.42 | 0.37 | 5.45
Chang et al., 2001^210^ | Reference | uhCG | 92
Chang et al., 2001^210^ | | rhCG 250 IU | 94 | 0.97 | 0.53 | 1.76 | 1.02 | 0.55 | 1.90
Chang et al., 2001^210^ | | rhCG 500 IU | 89 | 1.00 | 0.55 | 1.84 | 1.00 | 0.53 | 1.88
| | | 250 IU : Multiples 0.59 (0.24, 1.44); OHSS 0.98 (0.19, 4.98) 500 IU: Multiples 0.71 (0.30, 1.68); OHSS 2.93 (0.75, 11.4)
hCG vs. LH
European Recombinant LH Study Group, 2001^211^ | Reference | uHCG | 121
European Recombinant LH Study Group, 2001^211^ | | rLH (various doses) | 129 | 0.73 | 0.42 | 1.29 | 0.82 | 0.42 | 1.61
| | | No moderate/severe OHSS in single dose rLH, 12% in uHCG, but individual groups all < 55
Manau et al., 2002^212^ | Reference | uhCG | 15
Manau et al., 2002^212^ | | rLH | 15 | 1.00 | 0.23 | 4.31 | - | - | -
| | | Multiples 0.22 (0.01, 5.25); OHSS 4.62 (0.19, 111)
hCG vs. GnRH agonist after down- regulation with GnRh antagonist
Humaidan et al., 2005^213^ | Reference | hCG | 67
Humaidan et al., 2005^213^ | | GnRH agonist (buserelin) | 55 | 0.15 | 0.05 | 0.48 | - | - | -
| Down-regulation with antagonist | | Early loss 16.5 (2.06, 139)
Humaidan et al., 2006^214^ | Reference | hCG | 15
Humaidan et al., 2006^214^ | | Buserelin + hCG 12 hours later | 17 | 0.22 | 0.06 | 0.88 | - | - | -
Humaidan et al., 2006^214^ | | Buserelin + hCG 35 hours later | 13 | 0.87 | 0.41 | 1.84 | - | - | -
| Down-regulation with antagonist
Kolibianakis et al., 2005^215^ | Reference | hCG | 54
Kolibianakis et al., 2005^215^ | | GnRH agonist (triptorelin) | 52 | 0.14 | 0.03 | 0.58 | - | - | -
| Down-regulation with antagonist | | Early loss 6.61 (1.72, 25.4)
Engmann et al., 2008^216^ | Reference | hCG | 32
Engmann et al., 2008^216^ | | GnRH agonist (leuprolide) | 33 | 1.10 | 0.67 | 1.80 | 1.11 | 0.65 | 1.88
| Down-regulation with antagonist after OCP/agonist treatment | | OHSS signfifcantly lower 0.05 (0.001, 0.76); all subjects high risk for OHSS

Three studies randomizing women to urinary versus recombinant hCG showed no difference in pregnancy or live birth rates,^208^–^210^ although minor adverse events, especially injection site reactions, were more common with urinary hCG. In the one study that included two different doses of rhCG, there was a trend towards an increased rate of OHSS at the higher dose (RR 2.93; 95 percent CI 0.75–11.4).^210^

Two studies comparing uhCG to rLH did not demonstrate significant differences in pregnancy or live birth rate.^211,212^

Finally, four studies compared hCG to a GnRH agonist in women receiving a GnRH antagonist for down-regulation.^213^–^216^ Three showed significantly decreased pregnancy rates with the use of the agonist, with significantly higher early loss rates. A fourth, conducted in women considered at high risk of OHSS because of PCOS or prior response to stimulation, showed no difference in pregnancy rates, but significantly lower OHSS rates; this study used a different GnRH agonist and included suppression with oral contraceptives and GnRH agonist before beginning GnRH antagonists.

2. Other systematic reviews. We did not identify any other non-Cochrane reviews.

3. Cochrane reviews. The relevant Cochrane review (Table 27),^206^ updated February 2005, quantitatively found no difference in pregnancy or live birth rates between uhCG or rHCG, with a significant decrease in any adverse event, particularly injection site reactions (OR 0.47; 95 percent CI 0.32–0.70). Similarly, there was no difference in pregnancy or live birth rates between uhCG and rLH; an unpublished trial showed that doses of rLH required to prevent OHSS led to decreased pregnancy rate, and further development of the product for this indication was halted.

Table 27 Cochrane review, methods for follicular maturation^206^

Intervention | | N | Efficacy
Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
uhCG vs. rhCG
Reference | uhCG | 324
| rhCG | 423 | 0.98 | 0.71 | 1.36 | 0.98 | 0.69 | 1.39
| 4 studies, all post-2000 | | | | | Severe OHSS 1.89 (0.74, 4.82); any adverse event 0.47 (0.32, 0.70)
uhCG vs. rLH
Reference | uhCG | 136
| rLH | 144 | 0.93 | 0.53 | 1.63 | 0.94 | 0.50 | 1.76
| 2 studies, both post-2000 | | | | | Severe OHSS 0.82 (0.39,1.62)

4. Conclusions. Timing of hCG administration for follicular maturation is important for optimizing live birth rates - delays of 48 hours after one ultrasound threshold (at least three follicles of at least 17 mm) resulted in significant decreases in live births. The optimal time and threshold have not been determined. There does not appear to be any difference in pregnancy or live birth rates, or other major outcomes, between rhCG and uhCG, although injection site reactions are more common with uhCG. In cycles using a GnRH antagonist for pituitary down-regulation, use of hCG is superior to use of a GnRH agonist in most women, although agonists significantly lowered the risk of OHSS without affecting pregnancy rate in one trial of high-risk women.

D. Methods for oocyte retrieval. The current standard of care for oocyte retrieval is transvaginal aspiration under ultrasound guidance.

1. Included studies. We identified one trial of different techniques for retrieval in PCOS patients, and seven trials comparing different methods for analgesia (Table 28). Branigan and colleagues^217^ compared a standard protocol, where only follicles with a diameter of at least 10 mm (those believed to have the greatest likelihood of a fertilizable ovum) were aspirated, to a “thorough” protocol, where any “possible” follicle, down to 4 mm, was aspirated, in women with PCOS scheduled for IVF; those women who did not conceive after IVF were followed. The “thorough” protocol resulted in a higher pregnancy rate (RR 15.1; 95 percent CI 0.91–250) subsequent to the IVF cycle. Results for the entire randomized group, which includes 31 women who conceived during the IVF cycle, were not presented. Cumulative pregnancy and live birth rates for both the IVF and non-IVF cycles would be preferable.

Table 28 Methods for oocyte retrieval

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Methods for retrieval
Branigan et al., 2006^217^ | Reference | Standard retrieval | 30
Branigan et al., 2006^217^ | | “Thorough” retrieval | 34 | 15.1 | 0.91 | 250 | - | - | -
| PCOS patients; pregnancy after IVF | | 0 pregnancies in standard group
Analgesia
Cerne et al., 2006^221^ | Reference | Paracervical block | 87
Cerne et al., 2006^221^ | | Preovarian block | 91 | 0.92 | 0.56 | 1.50 | - | - | -
| | | No difference in pain scores
Humaidan et al., 2006^222^ | Reference | Fixed frequency acupuncture | 76
Humaidan et al., 2006^222^ | | Mixed frequency electro-acupuncture | 76 | 0.91 | 0.61 | 1.34 | - | - | -
| | | No difference in pain scores
Stener-Victorin et al., 2003^223^ | Reference | Alfentanyl + paracervical block (no sedation) | 138
Stener-Victorin et al., 2003^223^ | | Electroacupuncture + paracervical block | 136 | 0.89 | 0.64 | 1.24 | - | - | -
| | | No difference in pain scores
Humaidan et al., 2004^218^ | Reference | Alfentanyl + paracervical block (with sedation) | 100
Humaidan et al., 2004^218^ | | Electroacupuncture + paracervical block | 100 | 0.85 | 0.49 | 1.48 | - | - | -
| | | Higher peri-procedural pain in electroacupuncture group, shorter hospital times and costs
Ng et al., 2001^219^ | Reference | Paracervical block + placebo | 75
Ng et al., 2001^219^ | | Paracervical block + conscious sedation | 75 | 0.93 | 0.44 | 1.96 | - | - | -
| | | Peri-procedural pain significantly higher with block alone
Lok et al., 2002^220^ | Reference | Physician-controlled sedation | 55
Lok et al., 2002^220^ | | Patient - controlled sedation | 55 | 0.55 | 0.21 | 1.46 | - | - | -
| | | Peri-procedural pain scores higher with patient-controlled, but patient preferences higher
Thompson et al., 2000^224^ | Reference | IV analgesia | 55
Thompson et al., 2000^224^ | | Inhalational analgesia | 57 | 1.46 | 0.51 | 4.15 | - | - | -
| | | No differences in pain scores

Choice of analgesia did not significantly affect pregnancy rates in any of the studies. In general, overall pain scores were similar between the interventions, although variations in the scales, as well as types and dosing of analgesic agents and doses used, prevent any between-study comparisons. In studies where one arm did not include some kind of sedation,^218,219^ or used a lower level of sedation,^220^ peri-procedural pain was significantly higher, although this did not appear to have any impact on overall patient preferences.

2. Other systematic reviews. We did not identify any non-Cochrane reviews.

3. Cochrane reviews. The relevant Cochrane review^225^ found no difference in pregnancy rates. Intraoperative pain scores by visual analog scale were significantly higher with electroacupuncture compared to standard treatment, as well as with patient controlled sedation compared to physician controlled sedation.

4. Conclusions. Choice of analgesia for oocyte retrieval does not appear to affect pregnancy rates. Techniques involving some form of sedation result in lower intraoperative pain, but this does not appear to adversely affect overall patient perceptions and satisfaction.

E. Methods for endometrial preparation in frozen-thawed transfer. In the setting of transfer of frozen-thawed embryos from previous cycles, controlled ovarian hyperstimulation is obviously not necessary, but methods to improve preparation of the endometrium for implantation are frequently used. Since frozen embryo transfer from previous cycles is one potential way to maximize cumulative pregnancy rates while minimizing the risk of multiple gestations (see the section on the number of embryos transferred [section G under “The Embryo”], below), identifying the optimal method for preparation should be a high priority.

1. Included studies. Two studies compared the use of estrogen with and without a GnRH agonist (Table 29). Both were relatively large. In one,^226^ the GnRH agonist used did not significantly improve pregnancy rates; in the other,^227^ both pregnancy and live birth rates were significantly improved with the use of the agonist (RR for live birth 2.30; 95 percent CI 1.15–4.62). Both the type of agonist and the estrogen formulation used differed between the two studies. A third, smaller study^228^ compared regimens in women with unsuppressed cycles and found no difference in rates with oral estradiol followed by vaginal progesterone when endometrial thickness reached 7 mm compared with FSH on cycle days 6, 8, and 10 plus hCG to trigger ovulation.

Table 29 Methods for pituitary down-regulation - endometrial preparation for frozen-thawed embryo transfer

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
GnRH agonist vs. none with artificial endometrial preparation
Dal Prato et al., 2002^226^ | Reference | No agonist + transdermal estradiol | 150
| Agonist (triptorelin) + transdermal estradiol | 146 | 0.85 | 0.54 | 1.32 | - | - | -
El-Toukhy et al., 2004^227^ | Reference | No agonist + oral estrogen | 117
| Agonist (buserelin) + oral estrogen | 117 | 1.57 | 1.05 | 2.34 | 2.30 | 1.15 | 4.62
Estradiol + progesterone vs. FSH in unsuppressed cycles
Wright et al., 2006^228^ | Reference | No agonist + estrogen | 99
| No agonist + FSH | 100 | 0.91 | 0.42 | 1.96 | - | - | -

2. Other systematic reviews. We did not identify any other systematic reviews.

3. Cochrane reviews. The most recent Cochrane review, published in January 2008,^229^ is summarized in Table 30. The effectiveness of no intervention (natural cycle) transfer compared to endometrial preparation was evaluated in only one small trial, with subsequent wide confidence intervals. There was insufficient evidence to draw conclusions about other regimens, although there was an overall trend to higher pregnancy rates with the addition of GnRH agonists to estradiol/progesterone.

Table 30 Cochrane review, endometrial preparation for frozen-thawed embryo transfer^229^

Interventions | | N | Efficacy
Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Relative Effect | Lower 95% CI | Upper 95% CI | Relative Effect | Lower 95% CI | Upper 95% CI
Estrogen /progesterone vs. natural cycle
Reference | Natural | 44
| Estrogen/ progesterone | 56 | 1.06 | 0.40 | 2.80
| 1 study, pre-2000
Estrogen/ progesterone vs. GnRH agonist + estrogen/progesterone
Reference | GnRH agonist + E/P | 353
| Estrogen/progesterone | 372 | 0.76 | 0.52 | 1.10 | 0.38 | 0.17 | 0.84
| 4 studies, 3 post-2000 | | | | | 1 study, post-2000,, n=234
Estrogen/progesterone vs. FSH
Reference | Estrogen/progesterone | 94
| FSH | 100 | 0.84 | 0.35 | 2.02
| 2 studies, 1 post-2000
GnRH agonist + estrogen/progesterone vs. clomiphene
Reference | GnRH a + E/P | 37
| Clomiphene | 67 | 0.42 | 0.12 | 1.47
| 1 study, post-2000
Estrogen/progesterone vs. clomiphene
Reference | Estrogen/progesterone | 52
| Clomiphene | 67 | 0.76 | 0.21 | 2.77
| 1 study, post-2000
hMG vs. clomiphene
Reference | hMG | 102
| Clomiphene | 107 | 0.46 | 0.23 | 0.92
| 1 study, pre-2000

4. Conclusions. There is insufficient evidence to determine the optimal method for endometrial preparation for frozen-thawed embryo transfer.

F. Methods for embryo transfer. Methods for fertilization, embryo culture, selection and timing of transfer are discussed below. In the majority of procedures in the United States, embryos are transferred back into the uterus using a thin transcervical catheter.

1. Included studies. Studies meeting inclusion criteria are shown in Table 31. Berkkanoglu and colleagues randomized patients to either standard transfer protocol or irrigation with embryo culture media.^230^ Although reported rates were similar for the two arms, a much larger number of randomized subjects were excluded from the flushing arm (48 vs. 12) in the analysis, a difference that seems unlikely to be random. When analyzed by intention-to-treat, pregnancy and live birth rates were significantly lower in the flushing group (live birth RR 0.67; 95 percent CI 0.47–0.95).

Table 31 Methods for embryo transfer

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Pre-transfer irrigation
Berkkanoglu et al., 2006^230^ | Reference | No treatment | 120
| Irrigation of endometrial cavity prior to embryo transfer | 120 | 0.59 | 0.42 | 0.83 | 0.67 | 0.47 | 0.95
Type of provider
Bjuresten et al., 2003^231^ | Reference | Gynecologist | 51
| Midwife | 51 | 1.07 | 0.59 | 1.92 | - | - | -
Prophylactic antibiotics
Brook et al., 2006^232^ | Reference | No treatment | 130
Brook et al., 2006^232^ | | Antibiotic (750 mg co-amoxiclav 12 + 2 hours prior to transfer | 154 | 1.01 | 0.77 | 1.34 | - | - | -
| | | Bacterial contamination significantly reduced with antibiotic 0.79 (0.64, 0.98)
Transfer catheter type
Rhodes et al., 2007^233^ | Reference: | Cook catheter | 49
| Edwards-Wallace | 50 | 0.92 | 0.67 | 1.26 | - | - | -
Van Weering et al., 2002^235^ | Reference | TDT catheter | 657
| Cook catheter | 632 | 1.32 | 1.08 | 1.60 | - | - | -
McIlveen et al., 2005^234^ | Reference | Cooke | 75
| Wallace | 75 | 0.96 | 0.59 | 1.56 | - | - | -
Timing of catheter withdrawal
Martinez et al., 2001^236^ | Reference | Withdrawal 30 sec after transfer | 49
| Immediate withdrawal | 51 | 0.88 | 0.66 | 1.17 | - | - | -
Transfer media
Friedler, et al., 2007^237^ | Reference | No hyaluronic acid | 50
| Hyaluronic acid | 51 | 3.53 | 1.42 | 8.78 | 9.76 | 2.38 | 39.99
Korosec, et al., 2007^238^ | Reference | No hyaluronic acid | 37
Korosec, et al., 2007^238^ | | Hyaluronic acid | 28 | 1.44 | 0.75 | 2.77 | - | - | -
| | | Similar results in 214 subjects undergoing frozen-thawed transfer 1.10 (0.59, 2.03)
Mahani and Davar, 2007^239^ | Reference | No hyaluronic acid | 30
| Hyaluronic acid | 30 | 1.57 | 0.71 | 3.50 | 1.80 | 0.68 | 4.74

A Swedish study found no differences in pregnancy rates after ultrasound-guided transfer by a trained midwife or physician.^231^

A study of prophylactic antibiotics found no difference in pregnancy rates, despite a significantly reduced rate of bacterial contamination of the catheter.^232^

Two studies of different catheter types detected no difference in pregnancy rates.^233,234^ The third, comparing a catheter with a fixed metal obturator to a soft catheter where use of a metal obturator was optional, found significantly higher pregnancy rates with the soft catheter (RR 1.32; 95 percent CI 1.08–1.60).^235^

Timing of catheter withdrawal did not affect pregnancy rates.^236^

Three studies of embryo transfer media containing hyaluronic acid compared to standard media^237^–^239^ all showed improved pregnancy rates with media containing hyaluronic acid, with one^237^ showing significantly increased rates.

Ultrasound guidance of the transfer resulted in higher pregnancy rates in all but one of the studies identified (Table 32); this difference was significant in five of the eight studies. The one study which did not show any difference^240^ varied from the others in several ways. First, a single operator performed all of the procedures - an overall benefit of ultrasound guidance among multiple practitioners does not rule out the possibility of no difference for individuals. Second, there were two unplanned interim analyses involving the investigators rather than a separate statistical or data and safety monitoring board, a process which is somewhat unorthodox for clinical trials.

Table 32 Methods for embryo transfer - ultrasound guidance

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Coroleu et al., 2000^241^ | Reference | Clinical | 180
| Ultrasound | 182 | 1.48 | 1.15 | 1.90 | 1.62 | 1.23 | 2.13
De Camargo Martins et al., 2004^242^ | Reference | Clinical | 50
De Camargo Martins et al., 2004^242^
| Ultrasound | 50 | 1.40 | 0.82 | 2.39 | - | - | -
| All patients judged to be “easy” by mock transfer
Li et al., 2005^243^ | Reference | Clinical | 152
| Ultrasound | 178 | 1.48 | 1.06 | 2.07 | - | - | -
Matorras et al., 2002^244^ | Reference | Clinical | 260
Matorras et al., 2002^244^
| Ultrasound | 255 | 1.45 | 1.04 | 2.02 | 1.57 | 1.08 | 2.29
| | | Multiple pregnancy rate 1.10 (0.63, 1.92)
Corolau et al., 2006^245^ | Reference | Standard catheter | 95
Corolau et al., 2006^245^
| Echogenic catheter | 98 | 1.32 | 0.97 | 1.78 | - | - | -
| | | Twin rate among pregnancies significant higher with echogenic catheter 4.17 (1.31, 13.24)
Coroleu et al., 2002^246^ | Reference | Clinical | 91
Coroleu et al., 2002^246^
| Ultrasound | 93 | 1.74 | 1.06 | 2.87 | - | - | -
| | | Multiple pregnancy 0.56 (0.21, 2.91); miscarriage 0.98 (0.33, 2.91)
Tang et al., 2001^247^ | Reference | Clinical | 400
Tang et al., 2001^247^
| Ultrasound | 400 | 1.16 | 0.90 | 1.48 | 1.24 | 0.95 | 1.62
| | | Multiple pregnancy 1.34 (0.82, 2.18)
Kosmas et al., 2007^240^ | Reference | Clinical | 150
Kosmas et al., 2007^240^ | | Ultrasound | 150 | 1.00 | 0.77 | 1.30 | 1.24 | 0.95 | 1.62
| | | Multiple pregnancy 1.34 (0.82, 2.18)

2. Other systematic reviews. We did not identify any other non-Cochrane reviews.

3. Cochrane reviews. The relevant Cochrane review, updated November 2006, concluded that ultrasound guidance significantly improved both pregnancy (OR 1.49; 95 percent CI 1.29–1.72) and live birth rates (OR 1.40; 1.18–1.66).^248^ Multiple pregnancy rates were increased, but not significantly (OR 1.26; 0.91–1.75) and ectopic rates non-significantly decreased (OR 0.64; 0.25–1.61).

4. Conclusions. Pre-transfer irrigation does not improve pregnancy or live birth rate, and, based on an intention-to-treat analysis of the one study identified, significantly reduces both rates. There is no evidence that type of provider changes outcomes. Although pre-treatment with antibiotics significantly lowers measurable bacterial contamination, this does not translate into improved pregnancy or live birth rates. Hyaluronic acid containing media may result in higher pregnancy rates compared to other media.

Ultrasound-guided embryo transfer consistently results in substantial improvements (40 percent relative increase) in pregnancy and live birth rates compared to various “clinical touch” methods. The consistency of this finding and the size of the effect are striking considering that the majority of interventions covered in this review do not show significant differences.

G. Methods for luteal support. Aspiration of follicular cells during oocyte retrieval and suppression of GnRH can inhibit luteinization, which is necessary for progesterone production. The use of exogenous progesterone significantly increases pregnancy rates compared to placebo or no treatment.^249^ This section reviews studies published since 2000 that evaluate different progesterone-based regimens; varying routes of administration and timings of these regimens; alternatives to progesterone; and adjunctive treatments.

1. Included studies. Nine studies evaluated different formulations of progesterone (Table 33). In two studies, one with 205 subjects^250^ and another with 734,^251^ intramuscular progesterone resulted in higher pregnancy and live birth rates, with lower miscarriage rates in the larger study (RR 0.33; 95 percent CI 0.20,0.55), compared to vaginal progesterone. One study did not detect a significant difference between vaginal and oral progesterone.^252^ The remaining studies compared various formulations for vaginal administration; none detected a significant difference in pregnancy rates.

Table 33 Methods for luteal support - progesterone formulations

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Vaginal vs. intramuscular
Propst et al., 2001^250^ | Reference | Progesterone gel | 108
| IM progesterone | 99 | 1.62 | 0.94 | 2.81 | 2.05 | 1.13 | 3.73
Unfer et al., 2004^251^ | Reference | Vaginal progesterone | 373
Unfer et al., 2004^251^
| Intramuscular 17-hydroxyprogesterone | 361 | 1.59 | 1.27 | 2.00 | 1.50 | 1.17 | 1.92
| | | Miscarriage rate IM compared to vaginal 0.33 (0.2, 0.55)
Vaginal vs. oral
Chakravarty et al., 2005^252^ | Reference | Vaginal micronized progesterone | 351
| Oral dygesterone | 79 | 1.06 | 0.68 | 1.23 | - | - | -
Vaginal formulations
Kleinstein and Luteal Phase Study Group, 2005^253^ | Reference | Vaginal progesterone gel | 212
| Vaginal progesterone in oil | 218 | 1.14 | 0.81 | 1.60 | - | - | -
Geber et al., 2007^254^ | Reference | Micronized progesterone capsules | 122
| Micronized progesterone gel | 122 | 1.23 | 0.90 | 1.67 | 1.24 | 0.87 | 1.77
Ludwig et al., 2002^255^ | Reference | Micronized progesterone capsules | 53
| Micronized progesterone gel | 73 | 1.52 | 0.78 | 2.96 | 1.45 | 0.71 | 2.98
Tay and Lenton, 2005^256^ | Reference | Progesterone vaginal capsules | 55
Tay and Lenton, 2005^256^ | | Progesterone rectal | 35 | 0.99 | 0.53 | 1.85 | - | - | -
Tay and Lenton, 2005^256^
| Progesterone gel | 36 | 1.03 | 0.56 | 1.89 | - | -
| hCG | 35 | 0.99 | 0.53 | 1.85 | - | - | -
Zegers-Hochschild et al., 2000^257^ | Reference | IM progesterone | 262
| Vaginal ring | 243 | 1.00 | 0.79 | 1.26 | - | - | -
Ng et al., 2003^258^ | Reference | Progesterone suppository | 30
Ng et al., 2003^258^ | | Progesterone gel | 30 | 0.71 | 0.22 | 2.25 | - | - | -
| | | Patient preference for gel

Four studies evaluated hCG (Table 34). Compared to a standard GnRH agonist long protocol with no supplementation, hCG substantially increased pregnancy rates. This increase was not significant, probably due to the small sample size.^259^ In three studies comparing hCG to progesterone, there were no significant differences in pregnancy or live birth rates.^256,260^–^262^

Table 34 Methods for luteal support - hCG

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
hCG vs. placebo
Beckers et al., 2000^259^ | Reference | Long protocol, no support | 20
Beckers et al., 2000^259^
| Short protocol, no support | 20 | 7.06 | 0.33 | 151 | - | - | -
| Long, protocol, hCG | 20 | 10.0 | 0.49 | 203 | - | - | -
hCG vs. progesterone
Ludwig et al., 2001^260^ | Reference | Progesterone only | 191
Ludwig et al., 2001^260^
| hCG only | 77 | 1.01 | 0.69 | 1.47 | 0.80 | 0.43 | 1.50
| Progesterone + hCG | 145 | 0.79 | 0.47 | 1.33 | 1.01 | 0.63 | 1.60
Vimpeli et al., 2001^261^ | Reference | Vaginal progesterone | 45
| hCG | 44 | 0.87 | 0.35 | 2.15 | - | - | -
Martinez et al., 2000^262^ | Reference | Progesterone | 168
| hCG | 147 | 0.78 | 0.49 | 1.25 | - | - | -
Tay and Lenton, 2005^256^ | Reference: | Progesterone vaginal capsules | 55
Tay and Lenton, 2005^256^ | | Progesterone rectal | 35 | 0.99 | 0.53 | 1.85 | - | - | -
Tay and Lenton, 2005^256^
| Progesterone gel | 36 | 1.03 | 0.56 | 1.89 | - | - | -
| hCG | 35 | 0.99 | 0.53 | 1.85 | - | - | -

Four studies evaluated different regimens for the timing of beginning or ending progesterone supplementation (Table 35). None found a significant difference.

Table 35 Methods for luteal support - timing of beginning or ending progesterone supplementation

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Nyboe Andersen et al., 2002^263^ | Reference | Cessation of progesterone with + hCG | 150
| Continue progesterone for 3 weeks after hCG | 153 | 1.02 | 0.95 | 1.11 | 1.04 | 0.94 | 1.17
Baruffi et al., 2003^264^ | Reference | 400 mg vaginal progesterone day of transfer | 52
| 400 mg vaginal progesterone day of retrieval | 51 | 0.95 | 0.51 | 1.76 | - | - | -
Mochtar et al., 2006^265^ | Reference | Progesterone beginning day of embryo transfer | 127
Mochtar et al., 2006^265^
| Day of ovum retrieval | 127 | 0.95 | 0.66 | 1.37 | 1.03 | 0.64 | 1.70
| Day of hCG for ovulation trigger | 130 | 0.79 | 0.53 | 1.16 | 0.98 | 0.66 | 1.67
Williams et al., 2001^266^ | Reference | Progesterone day 3 after oocyte retrieval | 59
| Progesterone day 6 after oocyte retrieval | 67 | 0.73 | 0.52 | 1.03 | - | - | -

Finally, we reviewed studies of adjuncts to progesterone (Table 36). The addition of hCG on days 1, 4, and 7 after transfer significantly increased pregnancy rates (RR 2.31; 95 percent CI 1.06–5.03) in a subsequent cycle in poor responders.^267^ The addition of estrogens significantly increased pregnancy and live birth rates in GnRH agonist suppression protocols in two of three studies.^268,269^ Finally, a single administration of GnRH agonist added to progesterone and estrogen support increased pregnancy rates in patients using either a GnRH agonist or antagonist suppression protocol; the increase was significant in the antagonist group (RR 1.41; 95 percent CI 1.04–1.91).

Table 36 Methods for luteal support - adjuncts to progesterone

Study | Interventions | | N | Efficacy
Study | Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Progesterone + hCG
Fujimoto et al., 2002^267^ | Reference | IM progesterone | 51
Fujimoto et al., 2002^267^ | | IM progesterone + hCG days 1, 4, 7 after transfer | 63 | 2.31 | 1.06 | 5.03 | - | - | -
| Patients who did not conceive during 1^st^ cycle, low luteal E2
Ludwig et al., 2001^260^ | Reference | Progesterone only | 191
Ludwig et al., 2001^260^ | | hCG only | 77 | 1.01 | 0.69 | 1.47 | 0.80 | 0.43 | 1.50
| Progesterone + hCG | 145 | 0.79 | 0.47 | 1.33 | 1.01 | 0.63 | 1.60
Progesterone + estrogen
Unfer et al., 2004^268^ | Reference | Progesterone + placebo | 98
| Progesterone + phytoestrogens | 115 | 1.93 | 1.34 | 2.77 | 1.91 | 1.23 | 2.96
Lukaszuk et al., 2005^269^ | Reference | P only | 50
Lukaszuk et al., 2005^269^ | | P + 2 mg E2 | 47 | 1.42 | 0.89 | 2.26 | - | - | -
Lukaszuk et al., 2005^269^ | | P + 6 mg E2 | 69 | 1.61 | 1.06 | 2.45 | - | - | -
| | | Multiple pregnancies significantly higher with E2 regimens (0% P only, 30.4% 2 mg E2, 25.6% 6 mg E2)
Tay and Lenton, 2003^270^ | Reference | Progesterone only | 35
| Progesterone + E2 | 28 | 0.76 | 0.27 | 2.15 | - | - | -
Fatemi et al., 2006^271^ | Reference | 600 mg progesterone 1 day after retrieval | 100
Fatemi et al., 2006^271^ | | 600 mg progesterone + 4 mg E2 valerate | 101 | - | - | - | 1.14 | 0.73 | 1.79
| GnRH antagonist + rFSH | | Early pregnancy loss 0.98 (0.43, 2.26)
Progesterone + estrogen + GnRH agonist
Tesarik et al., 2006^272^ | Reference | P + E2 + Placebo | 300
Tesarik et al., 2006^272^ | | P + E2 +GnRH agonist (triptorelin) | 300 | 1.19 | 0.98 | 1.45 | - | - | -
| | | GnRH antagonist suppression: 1.41 (1.04, 1.91)

2. Other systematic reviews. We did not identify any other non-Cochrane reviews.

3. Cochrane reviews. The most recent Cochrane review was most recently updated in May 2004 (Table 37).^249^ Quantitative findings were largely similar to the qualitative findings described above. Intramuscular progesterone resulted in higher pregnancy and live birth rates compared to either oral or vaginal progesterone, although this was significant only for live births in the vaginal versus intramuscular group, likely because of the small number of subjects in the oral progesterone studies. Interestingly, multiple pregnancies were significantly increased with intramuscular compared to oral progesterone, even with the small sample size (OR 7.88; 95 percent CI 1.10–56.2), consistent with some implantation advantage. Significant differences were not detected between the different vaginal progesterone formulations.

Table 37 Cochrane review, methods for luteal support^249^

Interventions | | N | Efficacy
Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Relative Effect | Lower 95% CI | Upper 95% CI | Relative Effect | Lower 95% CI | Upper 95% CI
PROGESTERONE FORMULATIONS
Oral vs. IM progesterone
Reference | Oral | 44
| IM | 39 | 2.28 | 0.90 | 5.82 | 2.57 | 0.99 | 6.70
| 2 studies, 1 post-2000
Vaginal vs. IM progesterone
Reference | IM | 870
| Vaginal | 872 | 0.82 | 0.67 | 1.01 | 0.73 | 0.56 | 0.96
| 10 studies, 7 post-2000 | | | | | 6 studies, 3 post-2000, n=1044
Vaginal vs. oral progesterone
Reference | Oral | 164
| Vaginal | 159 | 1.51 | 0.93 | 2.45 | 1.32 | 0.79 | 2.19
| 2 studies, 1 post-2000
Vaginal gel vs. other vaginal
Reference | Other vag | 154
| Gel | 169 | 1.10 | 0.67 | 1.82 | 1.14 | 0.62 | 2.10
| 4 studies, 1 post-2000 | | | | | 2 studies, 1 post-2000, n = 225
hCG
hCG vs. placebo/no treatment
Reference | Control | 431
| hCG | 433 | 1.27 | 0.91 | 1.78 | 1.94 | 1.25 | 3.01
| 7 studies, 1 post-2000 | | | | | 5 studies, 1 post-2000, n = 645
Progesterone vs. hCG
Reference | hCG | 806
| Progesterone | 825 | 1.07 | 0.85 | 1.34 | 0.94 | 0.70 | 1.27
| 14 studies, 4 post-2000 | | | | | 9 studies, 2 post-2000, n = 1038
ADJUNCTS TO PROGESTERONE
Progesterone + hCG vs. progesterone
Reference | Progesterone | 576
| Progesterone + hCG | 575 | 1.10 | 0.84 | 1.43 | 1.05 | 0.69 | 1.60
| 8 studies, 4 post-2000 | | | | | 3 studies, 1 post-2000
Progesterone + estrogen vs. progesterone alone
| Progesterone | 85
| Prog + Estrogen | 78 | 0.89 | 0.43 | 1.84 | 0.89 | 0.34 | 2.32
| 2 studies, 1 post-2000 | | | | | 1 study, pre-2000, n = 100

hCG was significantly better than placebo in terms of live birth rates (OR 1.94; 95 percent CI 1.25–3.01) and miscarriages (OR 0.27; 0.11–0.61). Rates of multiple gestation (OR 2.77; 0.47–16.5) and moderate/severe OHSS (OR 11.17; 1.45– 86.2) were higher.

The addition of hCG to progesterone did not significantly increase pregnancy or live birth rates. In the two studies included in the meta-analysis, the addition of estrogen did not improve pregnancy or live birth rates; however, all three of the studies published subsequent to the Cochrane review do show improved rates.

4. Conclusions. Some form of luteal support is necessary with IVF, since both progesterone and hCG result in improved pregnancy rates compared to no treatment. Although there is no detectable difference between oral progesterone and the various formulations of vaginal progesterone, both result in lower pregnancy and live birth rates compared to intramuscular progesterone. The addition of estrogen to progesterone may improve outcomes, although additional larger studies are needed to confirm these findings. Finally, adding stimulation with a GnRH agonist to progesterone and estrogen in patients down-regulated with a GnRH antagonist improves live birth rates.

H. Other adjunct treatments. A variety of adjunctive treatments have been proposed to help improve pregnancy and live birth rates, decrease multiple pregnancy rates, or prevent complications related to IVF, in both first-line treatment and in patients who either have a worse prognosis or have failed previous therapy.

1. Included studies. We identified seven studies of medical therapy (Table 38). Two involved vasoactive agents^273,274^ and did not detect any significant differences. Five other studies involved the use of aspirin, with or without a corticosteroid, or a non-steroidal anti-inflammatory drug (NSAID). Only one showed a significant effect: in a placebo-controlled trial, administration of the NSAID piroxicam 1 day prior to embryo transfer increased pregnancy rates by almost 70 percent (RR 1.69; 95 percent CI 1.14–2.50).^275^

Table 38 Medical therapy

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Vasoactive agents
Battaglia et al., 2002^273^ | Reference | Placebo | 19
| L-arginine | 18 | - | - | - | 0.53 | 0.15 | 1.80
Pinheiro et al., 2003^274^ | Reference | No treatment | 45
Pinheiro et al., 2003^274^ | | Terbuatline 10 mg/day × 15 days at oocyte retrieval | 90 | 1.00 | 0.57 | 1.75 | - | - | -
| Ritodrine 20 mg/day, same schedule | 90 | 0.77 | 0.42 | 1.40 | - | - | -
Anti-inflammatory/immune system modulation
Duvan et al., 2006^276^ | Reference | No treatment | 40
Duvan et al., 2006^276^ | | Aspirin 100 mg/day | 41 | 0.77 | 0.40 | 1.48 | - | - | -
Duvan et al., 2006^276^ | | Prednisolone 10 mg/day | 50 | 1.26 | 0.74 | 2.13 | - | - | -
| Aspirin + prednisolone | 56 | 0.97 | 0.55 | 1.69 | - | - | -
Moon et al., 2004^275^ | Reference | Placebo 1–2 hr prior to transfer | 94
| Piroxicam 10 mg/day prior to transfer | 94 | 1.69 | 1.14 | 2.50 | - | - | -
Pakkila et al., 2005^277^ | Reference | Placebo from gonadotropins until menses or pregnancy test
| Aspirin 100 mg/day | | - | - | - | 0.87 | 0.57 | 1.34
Ubaldi et al., 2002^278^ | Reference | Aspirin 100 mg/day | 156
| Aspirin + prednisolone 5 mg/BID from day 1 of stimulation for 4 weeks | 159 | 0.98 | 0.79 | 1.23 | 1.07 | 0.81 | 1.41
Urman et al., 2000^279^ | | No treatment | 136
| Aspirin 80 mg/day from start of hMG through negative pregnancy test or +FHR | 139 | 0.91 | 0.69 | 1.21 | - | - | -

Six studies evaluated non-medical adjuncts (Table 39). Cha and Wirth found a two-fold higher pregnancy rate in subjects randomized to receiving intercessory prayer, where strangers prayed specifically for success (RR 2.07; 95 percent CI 1.34–3.22).^280^ We did not identify any similar studies, and this particular one raised multiple methodological questions, including issues regarding informed consent. Three studies of acupuncture all showed improvement in pregnancy and/or live birth rates.^281^–^283^ The three studies differed in the nature of the intervention, as well as the nature of the control - ranging from no acupuncture to acupuncture with a “sham” needle to active acupuncture of points thought to be unrelated to reproduction - making interpretation of the results difficult. Finally, a large Australian study found no differences in pregnancy rates between couples who were asked to abstain from intercourse around the time of embryo transfer and those who were encouraged to engage in intercourse at this time.^284^

Table 39 “Non-medical” adjuncts

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Complementary/alternative medicine
Intercessory prayer
Cha and Wirth, 2001^280^ | Reference | No prayer | 99
| Prayer | 100 | 2.07 | 1.34 | 3.22 | - | - | -
Pre-treatment counseling
Chan et al., 2006^285^ | Reference | No counseling | 126
| Eastern Body-Mind-Spirit counseling | 101 | 1.25 | 0.61 | 2.57 | - | - | -
Acupuncture
Smith et al., 2006^281^ | Reference | Placebo acupuncture (blunt needles) | 108
Smith et al., 2006^281^ | | Active acupuncture | 110 | 1.24 | 0.80 | 1.90 | 1.38 | 0.86 | 2.23
| Immediately before and after transfer
Dieterle et al., 2006^282^ | Reference | Placebo acupuncture (acupuncture on points not related to fertility) | 109
Dieterle et al., 2006^282^ | | Active acupuncture | 116 | 2.16 | 1.30 | 3.58 | 2.07 | 1.19 | 3.59
| 30 minutes before and 30 minutes after transfer
Westergaard et al., 2006^283^ | Reference | No acupuncture | 100
Westergaard et al., 2006^283^
Westergaard et al., 2006^283^ | | Acupuncture day of embryo transfer | 100 | - | - | - | 1.76 | 1.11 | 2.79
| Acupuncture day of transfer + 2 days later | 100 | - | - | - | 1.26 | 0.74 | 2.16
| | | Day of ET + 2 days later vs. day of ET only 0.71 (0.45, 1.10); miscarriage rate highest (33%) day of ET + 2 days later (15% and 21%)
Peri-transfer abstinence vs. intercourse
Tremellen et al., 2000^284^ | Reference | Abstinence | 236
| Peri-transfer intercourse | 242 | 1.18 | 0.8 | 1.73 | - | - | -

Finally, several trials of treatments in patients with a lower probability of a successful pregnancy because of known co-conditions or previous ART failure showed benefit (Table 40). Treatment with nitroglycerin,^286^ heparin and aspirin,^287^ IV immunoglobulin,^288^ or letrozole^289^ did not improve pregnancy rates in women with previous poor ovarian response. However, in patients without previous endometrial imaging, hysteroscopy and treatment of any discovered pathology significantly improved both pregnancy and live birth rates compared to repeat treatment without hysteroscopy (RR for live birth 1.70; 95 percent CI 1.22–2.37).^290^

Table 40 Adjuncts in patients with poor prognosis

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Previous poor response/implantation failure
Ohl et al., 2002^286^ | Reference | Placebo | 68
Ohl et al., 2002^286^ | | Nitroglycerin 5 mg patch daily from day before transfer until +hCG or menses | 70 | 0.86 | 0.48 | 1.55 | - | - | -
| Previous implantation failure
Rama et al., 2006^290^ | Reference | No hysteroscopy | 255
Rama et al., 2006^290^ | | Hysteroscopy/treatment of pathology | 265 | 1.64 | 1.28 | 2.10 | 1.70 | 1.22 | 2.37
| Previous failure
Stern et al., 2003^287^ | Reference | Placebo heparin + aspirin, day of transfer through hCG | 74
Stern et al., 2003^287^ | | Heparin 5000 u BID + 100 mg aspirin/day | 69 | - | - | - | 1.03 | 0.46 | 2.26
| Women with auto-antibodies , previous failure
Stephenson and Fluker, 2000^288^ | Reference | Placebo | 26
Stephenson and Fluker, 2000^288^ | | IV immunoglobulin within 72 hr preceding transfer, 4 wk later if +hCG | 25 | 1.26 | 0.32 | 5.16 | - | - | -
| 2 or more previous failures
Goswami et al., 2004^289^ | Reference | rFSH | 25
Goswami et al., 2004^289^ | | rFSH + letrozole | 13 | 0.96 | 0.29 | 3.23 | - | - | -
| Poor ovarian response
Age > 40
Avrech et al., 2004^299^ | Reference | hMG only | 73
| hMG + buserelin | 146 | 0.69 | 0.29 | 1.63 | 1.17 | 0.31 | 4.38
Tesarik et al., 2005^292^ | Reference | Placebo | 50
| Growth hormone 8 IU from day 7 until 1 day post-ovulation | 50 | - | - | - | 5.50 | 1.28 | 23.6
Keay et al., 2001^291^ | Reference | Placebo | 145
Keay et al., 2001^291^ | | Dexamethasone 10 mg/day | 145 | 1.56 | 1.00 | 2.44 | - | - | -
| | | Overall cancellation rate significantly lower in dexamethasone group 0.48 (95% CI 0.23,0.98)
PCOS
Tang et al., 2006^293^ | Reference | Placebo | 49
Tang et al., 2006^293^ | | Metformin 850 mg/day from 1^st^ day of down regulation to egg retrieval | 52 | 2.00 | 0.95 | 4.21 | 2.67 | 1.15 | 6.22
| PCOS | | Severe OHSS significantly lower in metformin group 0.19 (0.04, 0.82)
Kjotrod et al., 2004^294^ | Reference | No treatment | 36
Kjotrod et al., 2004^294^ | | Metformin 1000 mg BID at least 16 weeks until ovulation trigger | 37 | 1.16 | 0.71 | 1.87 | 1.06 | 0.54 | 2.09
| PCOS | | OHSS lower in metformin group, small numbers 0.19 (0.02, 1.59)
Endometriosis
Rickes et al., 2002^295^ | Reference | No pre-treatment | 55
Rickes et al., 2002^295^ | | GnRH agonist pre-treatment | 55 | 3.33 | 0.96 | 11.54 | - | - | -
| | | Cycles/patient: 1.7; control group started sooner post-surgery
Surrey et al., 2002^296^ | Reference | No pre-treatment | 26
Surrey et al., 2002^296^ | | GnRH agonist pre-treatment | 25 | - | - | - | 2.93 | 0.84 | 10.25
| | | Cycles/patient 1.0; control group started sooner post-surgery
Demirol et al., 2006^297^ | Reference | No surgery | 50
| Laparoscopic removal of endometrioma | 49 | 0.91 | 0.54 | 1.54 | - | - | -
Radiologic findings
Kontoravdis et al., 2006^298^ | Reference | No surgery | 15
Kontoravdis et al., 2006^298^ | | Laparoscopic salpingectomy | 50 | - | - | - | 5.10 | 0.74 | 35.2
Kontoravdis et al., 2006^298^ | | Laparoscopic tubal occlusion | 50 | | | | 6.90 | 1.01 | 46.9
Kontoravdis et al., 2006^298^ | | Either surgery | 100 | | | | 6.00 | 0.89 | 40.5
| Hydrosalpinges | | | | | Salpingectomy vs. occlusion 0.74 (0.45, 1.21)
Qublan et al., 2006^300^ | Reference | No aspiration | 46
| Cyst aspiration prior to oocyte retrieval | 76 | 1.21 | 0.32 | 4.61 | - | - | -

In women aged 40 or older, the addition of dexamethasone^291^ or growth hormone^292^ both significantly improved outcomes.

In women with PCOS, the addition of metformin reduced the incidence of OHSS and increased pregnancy and live birth rates.^293,294^ Both studies were small (52 or fewer subjects/arm), but the differences were significant in the study by Tang and colleagues (RR for live birth 2.67; 95 percent CI 1.15–6.22; for OHSS, 0.48; 0.23, 0.98).^293^

In women with known endometriosis, pre-treatment with a GnRH agonist for 3–6 months prior to initiating an IVF cycle increased pregnancy rates three-fold, although both studies were too small to detect a significant difference.^295,296^ The study by Rickes and colleagues^295^ is also notable as one of the few IVF studies where cumulative rates over several cycles were used as the endpoint. Laparoscopic removal of endometriomas detected prior to IVF did not improve pregnancy rates significantly.^297^

In patients with hydrosalpinges detected prior to IVF, laparoscopic occlusion or salpingectomy increased live birth rates five- to six-fold.^298^ The lower bound of the 95 percent CIs crossed 1.0 for both surgeries combined, but there were only 15 subjects in the no treatment arm, as opposed to 50 in each of the surgical arms. Ectopic pregnancy rates were not evaluable.

2. Other systematic reviews. We did not identify any other non-Cochrane reviews.

3. Cochrane reviews. There are five relevant Cochrane reviews on adjuncts for IVF (Table 41). Reviews of low-dose aspirin (7 studies with over 1200 subjects)^301^ and glucocorticoids (13 studies with over 1700 subjects)^302^ did not find significant treatment effects.

Table 41 Cochrane reviews, adjunct therapies for IVF

Interventions | | N | Efficacy
Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Relative Effect | Lower 95% CI | Upper 95% CI | Relative Effect | Lower 95% CI | Upper 95% CI
Aspirin^301^
Reference | Control | 622
| Aspirin | 618 | 1.09 | 0.93 | 1.28 | 0.94 | 0.63 | 1.39
| 7 studies, 4 post-2000 | | | | | 2 studies, 1 post-2000, n = 401
Steroids^302^
Reference | Control | 865
| Glucocorticoids | 894 | 1.15 | 0.93 | 1.43 | 1.21 | 0.67 | 2.19
| 13 studies, 3 post-2000 | | | | | 3 studies, all pre-2000, n = 424
Growth hormone^303^
| Placebo | 48
| GH | 43 | 1.18 | 0.41 | 3.37 | 1.17 | 0.38 | 3.59
| 3 studies, all pre-2000 | | Poor responders (3 studies, all pre-2000, n = 74, live birth rate increased 4.37 (1.06, 18.3)
Endometriosis^304^
Reference | Control | 77
| Down-regulation | 88 | 4.28 | 2.00 | 9.15 | 9.19 | 1.08 | 78.2
| 3 studies, 2 post-2000 | | | | | 1 study, pre-2000, n = 67
Surgery^305^
Reference | No surgery on tube | 134
| Salpingectomy | 161 | 1.75 | 1.07 | 2.86 | 2.13 | 1.24 | 3.65
| 3 studies, all pre-2000 | | | | | Ectopic 0.42 (0.01, 2.14)

The review of growth hormone^303^ did not find an overall significant treatment effect (OR 1.18; 95 percent CI 0.41–3.37). However, three studies of growth hormone in poor responders published prior to 2000 with a total of 74 subjects had a significant improvement in live birth rates (OR 4.37; 95 percent CI 1.06–18.3). This is consistent with the study by Tesarik and colleagues,^292^ which found a five-fold higher live birth rate with growth hormone in women over 40.

Prolonged pre-IVF down- regulation with a GnRH agonist significantly improved pregnancy and live birth rates (OR 9.19; 95 percent CI 1.08–78.2) in three studies with a total of 165 subjects.^304^

Surgical treatment of hydrosalpinges significantly improved pregnancy and live birth rates based on three pre-2000 studies with a total of 295 subjects (OR for live birth 2.13; 95 percent CI 1.24–3.65).^305^ This is consistent with the findings of Kontoravdis and colleagues described above.^298^

4. Conclusions. Based on the available evidence, vasoactive agents such as nitroglycerin, beta-agonists, or l-arginine do not improve pregnancy or live birth rates in either first-time or poor prognosis IVF patients. Low-dose aspirin does also not appear to have any effect. The NSAID piroxicam significantly improved pregnancy and live birth rates in a general IVF population, and further studies of NSAIDs are warranted. Randomized trials of intercessory prayer and acupuncture showed benefit, but there are remaining methodological questions which need to be addressed.

Dexamethasone and growth hormone both improved pregnancy and live births in women over 40 undergoing IVF; the growth hormone findings are consistent with earlier studies showing a benefit in poor responders. Metformin reduced the incidence of OHSS, and showed evidence of improvement in pregnancy and live birth rates, in women with PCOS undergoing IVF. Pre-treatment of women with endometriosis with a GnRH agonist for several months prior to IVF improves pregnancy and live birth rates, as do hysteroscopic removal of endometrial lesions and surgical removal or occlusion of hydrosalpinges.

I. Prevention of ovarian hyperstimulation syndrome.

1. Included studies. We identified two studies of interventions designed specifically as prophylaxis against OHSS (Table 42). Gokmen and colleagues^306^ found significant reductions in OHSS, with no difference in pregnancy rates, with the use of both hydroxyethyl starch and albumin. In contrast, in a much larger study, Bellver and colleagues^307^ found no differences, although the width of the confidence intervals cannot rule out benefit. This may represent differences in patient populations: the rate of OHSS in the no-treatment arm in the Gokmen study was 19.2 percent (16/83) compared to 6.9 percent (21/307) in the Bellver study. There are no other obvious sources for the differences - neither study used placebo or unblended assessment of the endpoints.

Table 42 Interventions to prevent OHSS

Study | Intervention | | N | Efficacy
Study | Intervention | | N | OHSS | | | Clinical/Ongoing pregnancy
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Albumin
Gokmen et al., 2001^306^ | Reference | No treatment | 83
Gokmen et al., 2001^306^ | | Prophylactic hydroxyethyl starch | 85 | 0.29 | 0.11 | 0.75 | 1.17 | 0.54 | 2.56
| Prophylactic IV albumin | 82 | 0.25 | 0.09 | 0.72 | 1.10 | 0.49 | 2.45
Bellver et al., 2003^307^ | Reference | No treatment | 307
| Albumin | 298 | 1.10 | 0.62 | 1.96 | 0.78 | 0.64 | 0.95

2. Other systematic reviews. We did not identify any other non-Cochrane reviews.

3. Cochrane reviews. There are three relevant Cochrane reviews. The first reviews the use of intravenous albumin^308^ and was most recently updated in December 2001. In five studies with a total of 378 subjects, the pooled OR for prevention of OHSS was significantly lower with albumin (OR 0.28; 95 percent CI 0.11–0.73), with no difference in pregnancy rates (OR 1.09; 0.65–1.83). The calculated number-needed-to-treat (NNT) to prevent one case of moderate to severe OHSS based on these estimates was 18. This may explain the difference between the previous studies and that of Bellver and colleagues: although the overall study was much larger, the rate was much smaller. The observed number of cases in the control group, 21, was close to the NNT, meaning that only one or two fewer cases would be expected to be observed in the albumin arm, a difference that would be very unlikely to be detectable.

Two other reviews addressed embryo freezing^309^ and coasting (withholding gonadotropins in patients judged to be at risk).^310^ There was insufficient evidence to draw any conclusions (two studies of embryo freezing with 26 and 125 subjects that did not show differences, and one study of coasting with a sample size of 30).

4. Conclusions. In one large study published subsequent to the last Cochrane update, IV albumin was not effective in reducing the incidence of moderate to severe OHSS in patients at risk, in contrast to the pooled analysis in the Cochrane review. This difference may be due to the low event rate in the larger study, which resulted in an absolute number of events too small to detect the estimated effect of albumin. Another study with a larger absolute number of subjects would be needed to resolve the issue. Given that many of the interventions discussed above, such as GnRH antagonists, may reduce the risk of OHSS, this may be difficult to accomplish.

### V. The Embryo

This section reviews those methods that are applied outside of the female partner's body, from fertilization up to the point of transfer.

A. Fertilization. Although IVF generally results in much higher per-cycle pregnancy rates than interventions that do not involve some type of assisted fertilization, it is possible that other methods might prove equally effective over a longer period of time, providing an alternative for some couples. In addition, although intracytoplasmic sperm injection (ICSI) is now considered the standard of care for couples with male factor infertility, especially severe male factor,^311^ whether or not ICSI improves outcomes compared to traditional IVF in other couples is not clear. Finally, it is possible that some technical aspects of the fertilization process might affect clinical outcomes.

1. Included studies. Studies meeting inclusion criteria are shown in Table 43. In a study comparing treatment in strategies in couples who had not conceived with non-IVF infertility treatment, Hughes and colleagues randomized 139 couples to a cycle of IVF within 6 weeks, or a 90-day “watchful waiting” period.^7^ Couples undergoing IVF were significantly more likely to conceive (RR 7.31; 95 percent CI 2.38–23.3) and to have a live birth (RR 20.8; 2.88–151.3). The cumulative 90-day pregnancy rate in the untreated couples was 4.3 percent, which is consistent with the pre-treatment pregnancy rate observed in other large trials.^6^

Table 43 Methods of fertilization

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Observation vs. IVF/ICSI
Hughes et al., 2004^7^ | Reference | 90 days wait | 71
Hughes et al., 2004^7^ | | Immediate IVF/ICSI | 68 | 7.31 | 2.28 | 23.3 | 20.8 | 2.88 | 151.3
| Failed previous non-IVF therapy | | Cumulative 90-day pregnancy rate in untreated arm 4.3%
IUI vs. IVF
Goverde et al., 2000^312^ | Reference | IUI alone | 86
Goverde et al., 2000^312^ | | IUI with mild stimulation | 85 | - | - | - | 1.25 | 0.81 | 1.93
Goverde et al., 2000^312^ | | IVF | 87 | - | - | - | 1.30 | 0.85 | 2.00
| | | Cycles/pt: 4.0 IUI with stimulation: Multiples 9.00 (1.17, 69.4) IVF: Multiples 6.40 (0.80, 51.0)
IVF vs. ICSI
Bhattacharya et al., 2001^313^ | Reference | IVF | 108
Bhattacharya et al., 2001^313^ | | ICSI | 107 | 0.79 | 0.59 | 1.07 | - | - | -
| Non-male factor infertility | | Multiples ICSI vs IVF 1.28 (0.71, 2.29)
Poehl et al., 2001^314^ | Reference | IVF | 45
Poehl et al., 2001^314^ | | ICSI | 44 | - | - | - | 0.68 | 0.34 | 1.35
| Tubal factor
Foong et al., 2006^315^ | Reference | IVF | 30
Foong et al., 2006^315^ | | ICSI | 30 | 1.00 | 0.60 | 1.66 | 1.07 | 0.63 | 1.81
| Unexplained
Technical aspects of fertilization
Kattera and Chen, 2003^316^ | Reference | 2 hours | 130
Kattera and Chen, 2003^316^ | | 20 hours | 129 | - | - | - | 0.59 | 0.43 | 0.82
| Co-incubation of sperm and oocytes
Morgia et al., 2006^317^ | Reference | HEPES | 351
Morgia et al., 2006^317^ | | No HEPES | 357 | 1.34 | 1.08 | 1.66 | - | - | -
| Media for ICSI
Wang et al., 2002^318^ | Reference | Thermostat | 40
Wang et al., 2002^318^ | | Non-thermostat | 52 | 0.69 | 0.31 | 1.54 | - | - | -
Wang et al., 2002^318^ | | Lens warmer | 29 | 2.07 | 1.09 | 3.93 | - | - | -
| Temperature control during ICSI

Goverde and colleagues^312^ randomized 178 couples with at least 3 years of infertility (1 year if male factor was a primary cause) to IUI alone, IUI with a mild stimulation protocol, or IVF for up to 6 cycles. Cumulative live births compared to IUI alone were not different with mild stimulation (RR 1.25; 95 percent CI 0.81–1.93) or IVF (RR 1.30; 0.85–2.00). Multiple rates were higher with stimulation (RR 9.00; 1.17–69.4) and IVF (RR 6.40; 0.80–51.0). Patients receiving IVF required fewer cycles.

Three studies comparing IVF to ICSI in patients with non-male factor infertility,^313^ tubal factor,^314^ or unexplained infertility^315^ did not demonstrate significant differences in outcomes between IVF or ICSI.

Three studies of technical aspects of fertilization did demonstrate significant differences in outcomes. Co-incubation of sperm and oocytes for 20 hours resulted in significantly lower live birth rates compared to 2 hour co-incubation (RR 0.59; 95 percent CI 0.43–0.83.^316^ Inclusion of n-hydroxyethylpiperazine-n-ethanesulfonate (HEPES) as a buffer in the media used for ICSI significantly reduced pregnancy rate (RR for non-HEPES media 1.34; 95 percent CI 1.08–1.66).^317^ Use of a lens warmer for temperature control during the ICSI procedure itself significantly improved live birth rates compared to a thermostat (RR 2.07; 95 percent CI 1.09–3.93).^318^

2. Other systematic reviews. We did not identify any other non-Cochrane reviews.

3. Cochrane reviews. The relevant Cochrane reviews^319,320^ included one trial each, both of which are described above.

4. Conclusions. IVF is superior to watchful waiting in couples who do not conceive after other treatment, but results in similar cumulative pregnancy rates compared to IUI alone or IUI with stimulation, with fewer multiples; time to pregnancy is faster with IVF. Based on the available evidence, outcomes are, at best, no better with ICSI than with IVF in couples without male factor infertility. Finally, technical aspects of fertilization can have a significant impact on clinical outcomes, and more randomized studies of these technical aspects should be encouraged.

B. Embryo culture.

1. Included studies. We identified two relevant studies that used random allocation of different culture methods and provided data on pregnancy and/or live birth. Quinn and Cooke^321^ compared two different media for fertilization and early embryonic development, each formulated to maintain a constant pH under an atmosphere of either five percent or six percent carbon dioxide, and detected no difference. Although the authors stated that the study was designed to show no difference, the sample size of 60 subjects was not adequate to demonstrate equivalence, since the lower bound of the confidence interval was well below 1.0 (RR 1.31; 95 percent CI 0.78–2.19).

Ben-Yosef and colleagues^322^ compared two different culture media in 349 subjects; differences were not significant, although there was a trend towards higher rates with the P1 media (RR for pregnancy 1.52; 95 percent CI 0.94–2.43; RR for live birth 1.47; 0.87–2.46).

2. Other systematic reviews. We did not identify any non-Cochrane systematic reviews.

3. Cochrane reviews. Culture conditions were not covered in any Cochrane reviews.

4. Conclusions. There is insufficient evidence to draw any conclusions about the impact of varying culture conditions on clinical outcomes of assisted reproduction.

C. Storage/freezing techniques. Generally, there are more embryos created in a given cycle than can be replaced. These embryos may be frozen (cryopreserved), then thawed and transferred to allow subsequent transfer in the event of a failed cycle or for continuing inability to conceive after a successful first IVF cycle. This section reviews the evidence on the technical aspects of cryopreservation. Other aspects of the IVF process that may have different outcomes in frozen-thawed embryos are discussed in the appropriate section.

1. Included studies. We identified one randomized trial meeting inclusion criteria. Balaban and colleagues randomized 196 couples to cryopreservation with embryo storage in either conventional storage straws, or high-security straws.^323^ Because embryos from multiple couples are stored in the same freezer tank, these high-security straws were designed to reduce the theoretical risk of cross-contamination with viral pathogens; physical properties also differ from conventional straws. Equivalent numbers of embryos were transferred in each group. Pregnancy rates were higher with the high-security straws, although the increase did not quite reach statistical significance (RR 1.38; 95 percent CI 0.95–2.00). Multiples were significantly increased (RR 3.42; 1.32–8.85).

2. Other systematic reviews. We did not identify any relevant non-Cochrane reviews.

3. Cochrane reviews. This topic is not covered by any published Cochrane review.

4. Conclusions. The only available evidence on cryopreservation techniques suggests that use of high-security straws for embryo storage increases pregnancy rates; the significant increase in multiple rates suggest that this may be due to improved implantation.

D. Selection of embryos for transfer. A consistent theme throughout this review is that implantation of the embryo is the critical step in determining the outcome of most of the interventions considered here. Improved implantation is the ultimate goal of much of the active research in reproductive medicine; as will be discussed in the section on longer term outcomes, abnormal implantation, resulting from underlying maternal or embryonic characteristics, treatment-specific factors, or both, may contribute to the observed increased risk of certain adverse pregnancy outcomes in infertility patients. The interventions described below - methods for embryo selection for transfer, methods for preparing the embryo for transfer, and number of embryos to transfer - are all aimed at maximizing the likelihood of at least one successful implantation, ideally without multiple gestation.

1. Included studies. Included studies are shown in Table 44. We identified two randomized trials of two methods for selecting embryos with the highest likelihood of successful implantation.^324,325^ Both studies randomized couples to one of two methods. In one arm, selection was based on day 3 morphology and progression scores, and pronuclear morphology assessed on day 1. In the other arm, a score based on the status of zygote cleavage into two cells was added. In both studies, pregnancy rates were not significantly different between arms.

Table 44 Selection of embryos for transfer

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Embryo scoring
Chen and Kattera, 2006^324^ | Reference | Day 3 morphology + day 1 morphology | 165
| Above + day 1 cleavage | 165 | 0.87 | 0.61 | 1.25 | - | - | -
Emiliani et al., 2005^325^ | Reference | Score only | 90
Emiliani et al., 2005^325^ | | Score + cleavage | 94 | 1.13 | 0.70 | 1.82 | - | - | -
| Single embryo transfer
Preimplantation genetic diagnosis (PGD)
Staessen et al., 2004^326^ | Reference | Control | 190
Staessen et al., 2004^326^ | | PGD | 199 | 0.71 | 0.46 | 1.10 | 0.72 | 0.43 | 1.21
| ≥ 37 years | | Multiples 1.43 (0.41, 4.96); number of embryos transferred significantly lower with PGD)
Mastenbroek, et al., 2007^327^ | Reference | Control | 206
Mastenbroek, et al., 2007^327^ | | PGD | 202 | 0.68 | 0.52 | 0.88 | 0.68 | 0.50 | 0.92
| 35–41 years | | All undergoing double embryo transfer

Two studies assessed the use of preimplantation genetic diagnosis (PGD) - a technique in which one or two embryonic cells are removed and examined for known chromosomal abnormalities - in selecting embryos in women 35 years or older.^326,327^ In the first study,^326^ both pregnancy and live birth rates were lower with PGD, although not significantly. Fewer embryos were transferred in the PGD group: approximately 25 percent of the biopsied embryos were genetically abnormal. In the second study,^327^ pregnancy and live birth rates were significantly lower with PGD; since all subjects had two embryos transferred, this difference could not be attributed to fewer transferred embryos.

2. Other systematic reviews. We did not identify any other non-Cochrane reviews.

3. Cochrane reviews. The relevant review^328^ included only studies of PGD. In addition to the paper by Staessen and colleagues described above,^326^ a published abstract with an additional 39 subjects was included. Summary odds ratios showed significant reductions in pregnancy rates with PGD (OR 0.56; 95 percent CI 0.32–0.96), with a non-significant reduction in live birth rate (OR 0.64; 0.37–1.09).

4. Conclusions. Although methods for evaluating embryo quality are an active area of research, and various methods are used clinically, we identified only two studies that compared the outcome of two different scoring methods in a randomized trial; neither showed a significant difference in pregnancy rates. Preimplantation genetic diagnosis reduces pregnancy rates when used in women of “advanced maternal age” (a criterion which varies somewhat, but generally includes women aged 35 years or older).

E. Preparation for transfer. Assisted hatching is a procedure that either removes or thins a portion of the outer coat of the embryo, the zona pellucida, based on the hypothesis that unfavorable chemical and physical changes to the zona during embryo culture are a barrier to successful implantation.^329^ A variety of methods are used, including laser, mechanical, or chemical disruption.

1. Included studies. Included studies are shown in Table 45, separated by patient population. In four studies in couples with at least one previous failed IVF attempt, assisted hatching generally improved pregnancy and live birth rates, although differences were significant in only one study each for all patients,^330^ a subgroup with two or more previous failures,^331^ and older women.^332^ Multiples were increased, significantly in one study.^330^

Table 45 Assisted hatching

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Previous failure
Ma et al., 2006^344^ | Reference | Control | 83
Ma et al., 2006^344^ | | Acid assisted hatching | 85 | 1.57 | 0.95 | 2.61 | 1.30 | 0.72 | 2.37
| Previous failure, oligospermia | | Multiples 1.5 (0.64, 1.47)
Petersen et al., 2005^331^ | Reference | Control | 75
Petersen et al., 2005^331^ | | ¼ laser hatching | 75 | 1.62 | 0.87 | 2.98 | 1.31 | 0.68 | 2.50
| At least 1 previous failure | | 2 or more previous failures: pregnancy 3.33 (0.99, 11.2); live birth 3.00 (0.88, 10.2)
Rufas-Sapir, et al., 2004^332^ | Reference | Control | 103
Rufas-Sapir, et al., 2004^332^ | | Mechanical hatching | 104 | 0.78 | 0.48 | 1.27 | - | - | -
| ≥ 3 previous failures | | Assisted hatching worse for women < 35 (15% vs. 35%), better for women > 40 (30% vs. 22%)
Jelinkova et al., 2003^330^ | Reference | Control | 129
Jelinkova et al., 2003^330^ | | Acidic assisted hatching | 128 | 1.49 | 1.08 | 2.04 | - | - | -
| ≥ 2 previous failures | | Multiples 3.02 (1.24, 7.37)
Frozen-thawed embryos
Nagy et al., 2005^333^ | Reference | No lysed cell removal (LCR) | 44
Nagy et al., 2005^333^ | | LCR + laser assisted hatching | 44 | 2.40 | 1.31 | 4.41 | - | - | -
| Frozen-thawed embryos
Sifer et al., 2006^335^ | Reference | Control | 64
Sifer et al., 2006^335^ | | Pronase assisted hatching | 61 | 0.96 | 0.46 | 2.01 | - | - | -
| 1^st^ frozen-thawed cycle
Ng et al., 2005^336^ | Reference | Control | 80
Ng et al., 2005^336^ | | Laser zona thinning | 80 | 0.83 | 0.38 | 1.82 | - | - | -
| Frozen-thawed embryos | | Multiples 3.60 (0.92, 14.1)
Primi et al., 2004^334^ | Reference | No hatching + placebo | 74
Primi et al., 2004^334^ | | Hatching + placebo | 84 | 0.27 | 0.09 | 0.80 | 0.33 | 0.09 | 1.20
Primi et al., 2004^334^ | | Hatching + steroid + doxycycline | 89 | 0.70 | 0.34 | 1.48 | 0.83 | 0.33 | 2.11
| Frozen-thawed embryos; laser
Maternal age/poor prognosis
Petersen et al., 2002^337^ | Reference | Control | 50
Petersen et al., 2002^337^ | | Laser zona thinning | 50 | 0.73 | 0.32 | 1.65 | 1.00 | 0.31 | 3.24
| ≥ 38 years
Frydman ett al., 2006^260^ | Reference | Control | 54
Frydman ett al., 2006^260^ | | Laser zona thinning | 49 | 0.89 | 0.54 | 1.48 | 0.76 | 0.39 | 1.47
| ≥ 37 years
Makrakis et al., 2006^339^ | Reference | Laser | 158
Makrakis et al., 2006^339^ | | Mechanical | 158 | 0.77 | 0.52 | 1.14 | 0.84 | 0.55 | 1.28
| ≥ 39 years
Primi et al., 2004^334^ | Reference | No hatching + placebo | 21
Primi et al., 2004^334^ | | Hatching + placebo | 22 | 0.57 | 0.16 | 2.10 | - | - | -
Primi et al., 2004^334^ | | Hatching + steroid + doxycycline | 23 | 0.91 | 0.31 | 2.71 | - | - | -
| 1^st^ fresh transfer, poor prognosis; laser
Nadir et al., 2005^340^ | Reference | Control | 30
Nadir et al., 2005^340^ | | Laser assisted hatching | 60 | 0.71 | 0.39 | 1.28 | - | - | -
| Endometriosis
Good prognosis
Sagoskin et al., 2007^341^ | Reference | Control | 81
Sagoskin et al., 2007^341^ | | Laser assisted hatching | 118 | 0.98 | 0.76 | 1.28 | 1.02 | 0.75 | 1.39
| Good prognosis
Baruffi et al., 2000^342^ | Reference | Control | 51
Baruffi et al., 2000^342^ | | Laser assisted hatching | 52 | 0.83 | 0.50 | 1.37 | - | - | -
| 1^st^ ICSI cycle
Isik et al., 2000^343^ | Reference | Zona intact blastocyst transfer | 22
Isik et al., 2000^343^ | | Zona free blastocyst transfer (chemical) | 24 | 1.38 | 0.79 | 2.39 | 1.68 | 0.75 | 3.77
| > 5 cleavage-stage embryos

Assisted hatching significantly increased,^333^ decreased,^334^ or had no effect^335,336^ on pregnancy rates prior to transfer of frozen-thawed embryos; there is no obvious clinical or methodological explanation for the wide disparity in results.

None of the trials performed for advanced maternal age or other prognostic factors,^334,337^–^340^ or in good prognosis patients^341^–^343^ showed any significant benefit; point estimates for the relative risk were less than 1.0 for all but one study.^343^

2. Other systematic reviews. We did not identify any non-Cochrane reviews.

3. Cochrane reviews. The relevant Cochrane review,^345^ updated in June 2005, includes 24 studies with over 2800 subjects, most predating 2000, and found a statistically significant improvements in pregnancy rates with assisted hatching (OR 1.29; 95 percent CI 1.10–1.52). Only six studies with 516 subjects reported live birth rates; the pooled OR was 1.19 (0.81–1.73).

Multiple pregnancy rate was significantly increased (OR 1.54; 95 percent CI 1.06–2.24). In subgroup analyses, benefit was primarily seen in patients with a poor prognosis or previous implantation failure.

4. Conclusions. Assisted hatching consistently improves pregnancy rates in couples with previous IVF failures; this difference was statistically significant in the largest trial and in pooled meta-analysis, both of which also showed a significant increase in multiple pregnancies. There is insufficient evidence to reach a conclusion about efficacy in other patient populations.

F. Timing of transfer. In natural cycles, fertilization occurs in the fallopian tube. After fertilization, the embryo progresses from a one-cell zygote (fertilization through the first 24 hours) and then, in a process referred to as cleavage, undergoes cell division, reaching eight cells by day 3; over the next several days, division continues and a small cavity, the blastocoel, forms, and differentiation of the cells into those destined to form the placenta and the fetus begins. By day 5, the blastocyst state, the embryo is approximately 80 to 100 cells and has reached the uterine cavity. Implantation generally occurs around day 7.^1^

In IVF, the same embryonic process occurs, but in a culture medium rather than in the mother's reproductive tract, and the embryo is replaced into the uterine cavity. There are trade-offs involved in determining the optimal time for transfer. Earlier transfer shortens the exposure time of the embryo to any adverse effects of the culture process and shortens the overall procedure time for both patients and clinics. Because the interactions between the maternal reproductive tract and the embryo are likely to be site-specific, transfer into the uterus at a stage when the embryo would normally be in the uterus rather than the fallopian tube may be more “physiologic,” and methods for evaluating the potential of the embryo for successful implantation are generally more reproducible at later stages.^346,347^

1. Included studies. Included studies are summarized in Table 46. Two studies compared day 1 transfer of zygotes to day 3 transfer and found either no significant difference^348^ or significantly lower pregnancy and live birth rates with zygote transfer.^349^

Table 46 Timing of transfer

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Day 3 vs. day 1 (zygote)
Dale et al., 2002^348^ | Reference | Day 3 | 202
Dale et al., 2002^348^ | | Day 1 | 205 | 0.95 | 0.74 | 1.22 | - | - | -
| 1^st^ cycle | | Multiples 0.60 (0.40, 0.89)
Jaroudi et al., 2004^349^ | Reference | Day 3 | 151
Jaroudi et al., 2004^349^ | | Day 1 | 151 | 0.62 | 0.43 | 0.89 | 0.64 | 0.42 | 0.99
| | | Multiples (twins) 0.56 (0.19, 1.62)
Day 3 vs. day 2
Bahceci et al., 2006^353^ | Reference | Day 3 | 235
Bahceci et al., 2006^353^ | | Day 2 | 237 | 1.73 | 1.17 | 2.56 | 1.70 | 1.07 | 2.72
| Poor ovarian response | | Multiple pregnancy 0.73 (0.3, 1.76)
Laverge et al., 2001^350^ | Reference | Day 3 | 372
Laverge et al., 2001^350^ | | Day 2 | 374 | - | - | - | 1.01 | 0.86 | 1.18
| | | Multiples 0.99 (0.69, 1.41)
Pantos et al., 2004^351^ | Reference | Day 3 | 81
Pantos et al., 2004^351^ | | Day 2 | 81 | 0.97 | 0.70 | 1.35 | 0.94 | 0.66 | 1.35
Pantos et al., 2004^351^ | | Day 6 | 81 | 0.77 | 0.54 | 1.11 | 0.57 | 0.36 | 0.90
| | | Day 2 multiples 1.10 (0.49, 2.45) Day 3 multiples 1.20 (0.55, 2.62)
Baruffi et al., 2003^352^ | Reference | Day 3 | 53
Baruffi et al., 2003^352^ | | Day 2 | 53 | 1.05 | 0.67 | 1.63 | - | - | -
| ICSI | | Multiples not reported
Day 3 vs. day 5 (blastocyst)
Kolibianakis et al., 2004^354^ | Reference | Day 3 | 234
Kolibianakis et al., 2004^354^ | | Day 5 | 226 | - | - | - | 1.04 | 0.80 | 1.35
| Randomized at time of initial evaluation | | Multiples 1.33 (0.74, 2.4)
Papanikolaou et al., 2006^355^ | Reference | Day 3 | 175
Papanikolaou et al., 2006^355^ | | Day 5 | 176 | 1.41 | 1.00 | 1.98 | 1.47 | 1.03 | 2.09
| 1st or 2nd cycle; randomized at initial visit | | Single embryo transfer
Montag et al., 2006^362^ | Reference | Day 3 | 90
Montag et al., 2006^362^ | | Day 4 | 95 | 0.60 | 0.38 | 0.96 | - | - | -
Montag et al., 2006^362^ | | Day 5 | 88 | 0.40 | 0.23 | 0.71 | - | - | -
| 3 embryos cultured/cycle
Bungum et al., 2003^361^ | Reference | Day 3 | 57
Bungum et al., 2003^361^ | | Day 5 | 61 | 0.83 | 0.61 | 1.13 | - | - | -
| 2 embryos day 3, 1 embryo day 5 | | No difference in twinning
Karaki et al., 2002^356^ | Reference | Day 3 | 82
Karaki et al., 2002^356^ | | Day 5 | 80 | 1.12 | 0.68 | 1.86 | - | - | -
| | | Multiples 0.82 (0.42, 1.62); ≥ triplets 0.26 (0.03, 2.24)
Levitas et al., 2004^357^ | Reference | Day 3 | 31
Levitas et al., 2004^357^ | | Day 5 | 23 | 1.68 | 0.51 | 5.59 | - | - | -
| ≥ 3 previous failed attempts
Papanikolaou et al., 2005^358^ | Reference | Day 3 | 84
| Day 5 | 80 | 1.63 | 1.12 | 2.37 | 1.73 | 1.14 | 2.63
Hreinsson et al., 2004^359^ | Reference | Day 2–3 | 80
Hreinsson et al., 2004^359^ | | Day 5–6 | 64 | 1.10 | 0.69 | 1.76 | 0.98 | 0.58 | 1.65
| | | Twins 0.57 (0.11, 2.81)
Hsieh et al., 2000^360^ | Reference | Day 5 | 201
| Day 2 | 158 | 1.12 | 0.86 | 1.45 | 1.09 | 0.80 | 1.49
Pantos et al., 2004^351^ | Reference | Day 3 | 81
Pantos et al., 2004^351^ | | Day 2 | 81 | 0.97 | 0.70 | 1.35 | 0.94 | 0.66 | 1.35
Pantos et al., 2004^351^ | | Day 6 | 81 | 0.77 | 0.54 | 1.11 | 0.57 | 0.36 | 0.90
| | | Day 2 multiples 1.10 (0.49, 2.45); Day 3 multiples 1.20 (0.55, 2.62)

In four studies comparing transfer on day 2 versus day 3, there was no advantage to day 2 transfer^350^–^352^ except in one large study of patients with a poor ovarian response (5 or fewer oocytes retrieved after stimulation).^353^ In this study with 472 subjects, day 2 transfer significantly improved both pregnancy and live birth rates (RR for live birth 1.70; 95 percent CI 1.07–2.72).

Ten studies compared day 3 transfer with blastocyst (day 5) transfer. Seven of the 10 ^354^–^360^ showed improved pregnancy and/or live birth rates with blastocyst transfer, with significant improvements in two.^355,358^ The 2006 study of Papanikolaou and colleagues^355^ is of particular interest, since randomization occurred at the time of entry into the trial (avoiding potential biases introduced by randomization at day 3), involved only single embryo transfer in both arms, and demonstrated a large enough difference that the study was stopped at the planned interim analysis. There were no observed differences in other studies in multiple gestation rates, although day 5 transfer did result in a lower number of embryos available for subsequent cryopreservation.^354^

Studies that showed no benefit may have been due to different numbers of transferred embryos^361^ or a more limited choice of embryos.^354,362^

2. Other systematic reviews. We did not identify any non-Cochrane systematic reviews.

3. Cochrane reviews. There are two relevant Cochrane reviews (Table 47). The first,^346^ updated in July 2003, found significant improvement in pooled estimates for pregnancy (OR 1.26; 95 percent CI 1.06–1.51), but not live birth (OR 1.07; 0.84–1.37) for day 3 compared to day 2 transfer. The benefit appeared limited to patients undergoing ICSI.

Table 47 Cochrane reviews, timing of transfer

Interventions | | N | Efficacy
Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Relative Effect | Lower 95% CI | Upper 95% CI | Relative Effect | Lower 95% CI | Upper 95% CI
Day 2 vs. day 3^346^
Reference | Day 2 | 1008
| Day 3 | 1019 | 1.26 | 1.06 | 1.51 | 1.07 | 0.84 | 1.37
| 10 studies, 3 post-2000 | | | | | 2 studies, 1 post-2000, n = 1200
Day 3 vs. day 5 (blastocyst)^347^
Reference | Day 2/3 | 1297
| Day 5/6 | 1260 | - | - | - | 1.35 | 1.05 | 1.74
| 17 studies, 15 post-2000 | | | | | 9 studies, all post-2000

The second review^347^ found a significantly higher pooled live birth rate for blastocyst transfer versus day 3 transfer of 1.35 (95 percent CI 1.05–1.74). Fewer embryos were frozen, with a greater number of cycles with no embryos transferred at all. In subgroup analysis, results were best in patients with a good prognosis, with high numbers of embryos available for transfer, and in trials where randomization occurred on day 3 rather than prior to cycle initiation.

4. Conclusions. The available evidence suggests that zygote transfer is, at best, no better than day 3 transfer and may result in worse pregnancy and live birth rates. Transfer on day 2 may produce better outcomes compared to day 3 in women with poor ovarian response, based on one large trial; pooled meta-analysis results suggest better pregnancy rates, but not necessarily live birth rates, in cycles where ICSI is used. Finally, blastocyst transfer results in better live birth rates than day 3 transfer, especially in patients with a good prognosis. The disadvantage of delaying transfer is a reduction in the number of embryos available for transfer and for cryopreservation.

These results suggest that there continue to be trade-offs between having greater overall numbers of embryos available for transfer versus transfer of fewer, but presumably “better” on average, embryos.

G. Number of embryos transferred. Finally, as a response to increased multiple rates, many European countries have placed regulatory limits on the number of embryos per transfer. The effect of reducing the number of transferred embryos has been tested in a number of clinical trials.

1. Included studies. Included studies are summarized in Table 48. Not surprisingly, transfer of a single embryo consistently resulted in lower pregnancy rates in a given cycle compared to transfer of two embryos,^363^–^366^ with a consistently significant reduction in multiples (almost all twins).

Table 48 Number of embryos transferred

Study | Intervention | | N | Efficacy
Study | Intervention | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Rel Eff | Lower 95% CI | Upper 95% CI | Rel Eff | Lower 95% CI | Upper 95% CI
Gardner et al., 2004^363^ | Reference | 2 blastocysts | 25
Gardner et al., 2004^363^ | | 1 blastocyst | 23 | 0.80 | 0.54 | 1.19 | - | - | -
| | | Multiples 0.01 (0.00, 0.95)
Lukassen et al., 2005^367^ | Reference | 1 IVF cycle, 2 embryos transferred | 54
Lukassen et al., 2005^367^ | | 2 cycles, 1 embryo transferred per cycle | 53 | 1.18 | 0.81 | 1.71 | 1.14 | 0.70 | 1.84
| 1^st^ cycle or previous successful IVF | | Multiples 0.06 (0.00, 0.95)
Heijnen et al., 2007^364^ | Reference | GnRH long protocol + 2 embryos | 199
Heijnen et al., 2007^364^ | | GnRH antagonist + single embryo | 205 | 0.91 | 0.75 | 1.11 | 0.87 | 0.67 | 1.13
| 1^st^ cycle or previous successful IVF; age < 38 | | Term live births equivalent (primary outcome); multiples 0.04 (0.01, 0.27) ; time to pregnancy faster with long protocol; OHSS 0.47 (0.19, 1.27)
Heijnen et al., 2006^368^ | Reference | 3 embryo transfers over max 3 cycles | 22
Heijnen et al., 2006^368^ | | 2 embryo transfers over max 4 cycles | 23 | 1.57 | 0.98 | 2.50 | 1.20 | 0.58 | 2.46
| 1^st^ cycle or previous successful IVF; age ≥ 38 | | Multiples 0.12 (0.01, 1.98)
Thurin et al., 2004^365^ | Reference | Double embryo transfer | 330
Thurin et al., 2004^365^ | | Single embryo transfer, followed by fresh frozen | 331 | 0.56 | 0.25 | 1.26 | 0.91 | 0.78 | 1.06
| 1^st^ or 2^nd^ IVF cycle | | Multiples 0.02 (0.001, 0.13)
Van Montfoort et al., 2006^366^ | Reference | Double | 154
Van Montfoort et al., 2006^366^ | | Single | 154 | 0.53 | 0.37 | 0.76 | - | - | -
| 1^st^ IVF cycle, good prognosis | | Multiples 0.04 (0.01, 0.6)

One of these studies^364^ compared transfer of two embryos after a traditional GnRH agonist long protocol to transfer of a single embryo after a GnRH antagonist in 404 subjects. The primary outcome was term live births; the study was designed as an equivalence trial, and term live birth met pre-specified equivalence criteria, although overall live birth rate was somewhat lower with single embryo transfer (RR 0.87; 95 percent CI 0.67–1.13). Multiples (RR 0.04; 0.01–0.27) and OHSS (RR 0.47; 0.19–1.27) were lower in the GnRH antagonist/single embryo transfer arm.

Three studies evaluated strategies that involved more than one cycle. Lukassen and colleagues^367^ compared one cycle of double embryo transfer to two cycles of single embryo transfer. There was not a significant difference in pregnancy or live birth rates, but multiples were significantly reduced with single embryo transfer. The study was underpowered to determine equivalence. Heijnen and colleagues^364^ compared transfer of three embryos per cycle over a maximum of three cycles to transfer of two embryos per cycle over a maximum of four cycles in women 38 or older. Pregnancy and live births were higher, and multiples lower with the strategy of two embryos over four cycles, but this study of only 45 subjects was underpowered.

A third, much larger study compared double embryo transfer to single embryo transfer with cryopreservation and transfer of the thawed frozen embryo in a second cycle if necessary.^365^ The study was designed as an equivalence study and did not meet the pre-specified lower bound difference of a 10 percent absolute difference; however, the lower bound was no worse than an 11.6 percent difference. Again, multiples were significantly reduced with single embryo transfer.

2. Other systematic reviews. We did not identify any non-Cochrane systematic reviews.

3. Cochrane reviews. Results of the most recent review^369^ are consistent with the findings discussed above (Table 49). Pooled live birth rate for double versus single transfer was 1.94 (1.47–2.55), with pooled odds of multiple gestation 23.55 (8.00–69.2).

Table 49 Cochrane reviews, number of embryos transferred^369^

Interventions | | N | Efficacy
Interventions | | N | Clinical Pregnancy | | | Ongoing Pregnancy/Live Birth
Relative Effect | Lower 95% CI | Upper 95% CI | Relative Effect | Lower 95% CI | Upper 95% CI
Single vs. double embryo transfer
Reference | Single | 456
| Double | 453 | 2.16 | 1.65 | 2.82 | 1.94 | 1.47 | 2.55
| 4 studies, 3 post-2000 | | | | | Multiple pregnancy 23.55 (8.00, 69.29)
Single fresh + single frozen vs. double
Reference | Single fresh + single frozen | 330
| Double | 331 | 1.21 | 0.89 | 1.64 | 1.19 | 0.87 | 1.62
| 1 study, post-2000 | | | | | Multiple pregnancy 62.8 (8.52, 463.6)
2 vs. 4 embryos
Reference | 4 embryos | 28
| 2 embryos | 28 | 0.75 | 0.26 | 2.16 | 0.35 | 0.11 | 1.05
| 1 study, pre-2000 | | | | | Multiples 0.44 (0.10, 1.97)

4. Conclusions. Although double embryo transfer results in higher pregnancy and live birth rates compared to single embryo transfer, multiple rates - almost all twins - are consistently higher. Strategies involving alternative methods for pituitary down-regulation, or involving multiple cycles with fewer embryo transfers per cycle, appear to result in similar live birth rates with fewer multiples.

## Longer Term Outcomes (Question 4)

### I. Research Question

What are the adverse outcomes of ovulatory drug-induced pregnancies and of pregnancies achieved with in vitro fertilization (IVF)? Is there evidence to link these adverse outcomes with the treatments and not the underlying maternal health or gestational age problems? For the mother, outcomes include preeclampsia, cesarean delivery, gestational diabetes, abruption, placenta previa, and breast and ovarian cancer. For the infant, outcomes include birth defects, prematurity, low birth weight, and long-term outcomes as available.

### II. Approach

The relative lack of data on fetal and neonatal outcomes in pregnancies after infertility treatment, especially IVF/ICSI, has been identified as a major research priority.^370^ Although the association between multiple pregnancies resulting from infertility treatments and preterm delivery and short-term neonatal morbidity and mortality has been recognized as an issue for some time,^25^ there is increasing evidence that even singleton pregnancies resulting from infertility treatments may be at increased risk for many adverse outcomes.^371^

In this section, we review the literature addressing maternal, fetal, and child outcomes during and after pregnancy (as well as any paternal outcomes reported). Fetal/neonatal outcomes include spontaneous abortion, ectopic pregnancy, abnormal test results in maternal screening for Down's syndrome and other aneuploidies, preterm delivery, low birth weight, and other outcomes. Maternal outcomes during pregnancy include preeclampsia, gestational diabetes, placental abnormalities, and psychological outcomes. Post-delivery outcomes for children include birth to 1 year (congenital anomalies, other physical outcomes), and 1 year and beyond (physical and neurodevelopmental outcomes). Maternal longer term outcomes include cancer and psychological outcomes.

We did not include cesarean section as an outcome. Although cesarean section rates are consistently elevated in women who conceive after infertility treatment,^372^ it is unclear how much of this risk is due to differences in obstetric conditions for which cesarean section is indicated, variations in practice between sites, and variations in the threshold for cesarean section among obstetricians and couples.

As noted in the sections above, data on pregnancy outcomes are lacking from most trials of infertility treatments. Given that most studies are underpowered to detect differences in pregnancy rates, it is not surprising that even those studies that do provide data are underpowered to detect outcomes that occur in only a fraction of pregnancies. The only option for examining these outcomes is observational data, either cohort or case-control studies. With the exception of cancer outcomes, the majority of studies were variations of cohort studies - outcomes of women who underwent infertility treatment were compared to outcomes of women who did not. Most of non-cancer studies labeled “case-control” were actually cohort studies with some sampling of women who were not exposed to infertility treatment.

Although we identified several very large population-based studies that provided valuable data on associations, it is important to emphasize that all of the caveats that apply to the interpretation of reported favorable treatment outcomes based on observational studies (including the potential for various types of bias and substantial confounding because of factors related to the selection of a given treatment in a given patient) should also be considered when interpreting the results of observational studies of adverse outcomes after treatment.

### III. Search Results

The flow of articles on this topic through the literature search and screening process is depicted in Figure 5.

Figure 5. Literature flow diagram - Question 4

### IV. Fetal/Neonatal Outcomes

As noted above, the relative lack of data on fetal and neonatal outcomes in pregnancies after infertility treatment, especially IVF/ICSI, has been identified as a major research priority.^370^ Although the association between multiple pregnancies resulting from infertility treatments and preterm delivery and short-term neonatal morbidity and mortality has been recognized as an issue for some time,^25^ there is increasing evidence that even singleton pregnancies resulting from infertility treatments are at increased risk for many adverse outcomes. This section reviews outcomes occurring from implantation through delivery.

A. Spontaneous abortion. Spontaneous abortion is common, occurring in 25 to 30 percent of all spontaneous conceptions.^373^ Maternal age is a particularly strong risk factor for both spontaneous abortion and infertility. In this section, we define spontaneous abortion or pregnancy loss as the loss of the entire pregnancy. Although loss of one or more fetuses in a multiple gestation with an ongoing pregnancy with at least one fetus is not uncommon, we focus here on loss of the entire pregnancy.

1. Included studies. In a prospective cohort of 3259 subjects attempting pregnancy, the spontaneous abortion rate was significantly higher in women who took longer than 12 months to conceive (RR 1.82; 95 percent CI 1.44–2.29).^374^ In a study based on the SART registry, spontaneous abortion rates were similar to those in the National Survey of Family Growth.^375^

Age was consistently a major risk for spontaneous abortion across all categories of assisted reproduction techniques.^375^–^377^

One strikingly consistent finding is that, once one or more fetal heart rates are identified, loss rates are significantly lower for twins than for singletons, especially in women under the age of 35.^375,378^–^381^ This suggests that, in the setting of multiple embryo transfer, factors related to implantation and placentation in either the mother, the embryo, or both, which lead to initiation of a multiple gestation also contribute to the ongoing viability of the pregnancy.

We identified several studies that compared loss rates with IVF versus ICSI. Most studies reported either increased^382^–^384^ or no difference^375^ in risk with ICSI; only one showed a significant decrease in loss rates with ICSI.^379^ This may reflect differences in the distribution of risk factors due to differences in uses of ICSI, as suggested by studies that found a significant difference only for ICSI performed for male factor infertility (0.73; 95 percent CI 0.53–1.00), and another smaller study which found a higher incidence of abnormal karyotypes with ICSI compared to IVF in the products of conception examined after losses.^385^

2. Other systematic reviews. We did not identify any other published reviews on this topic.

3. Conclusions. Spontaneous abortion does not appear to be more common after assisted reproduction after adjusting for known risks; observed differences between different methods appear to be related to differences in the patient population to which the methods are applied.

B. Ectopic pregnancy. Ectopic pregnancy is more common in pregnancies involving assisted reproduction than in spontaneous conceptions. Even heterotopic pregnancies (simultaneous intra- and extrauterine pregnancies) - which are so rare in spontaneous conceptions that the presence of an intrauterine pregnancy is used to rule out an ectopic pregnancy - appear to be more common after IVF/ICSI.^386^–^388^ As with the majority of adverse outcomes discussed in this section, it is unclear how much of this risk is associated with the underlying condition, the treatments used, or both. Damage to the fallopian tubes from previous infection or endometriosis is clearly a risk factor for both infertility and ectopic pregnancy, while superovulation and multiple embryo transfer increase the probability of heterotopic pregnancy simply by increasing the number of potential embryos that can implant. Abnormal implantation may be related to the underlying infertility, alterations in the normal process of implantation secondary to the treatments used, or both.

1. Included studies. Three relatively small studies examined differences in ectopic rates based on aspects of the procedure itself. Check and colleagues^389^ compared rates after fresh versus frozen embryo transfer in 2520 women; they did not detect a significant difference (RR 0.78 for frozen compared to fresh; 95 percent CI 0.45–1.34). Rates were also not significantly increased for fresh versus frozen blastocyst transfer in a smaller series of 744 blastocyst transfers.^390^ Jun and Milki^391^ reported a significantly higher incidence of ectopic pregnancies after assisted hatching in 623 pregnancies (RR 2.48; 1.05–5.82). However, none of these studies adjusted for potential confounders.

Two studies from the SART registry provided relevant data on ectopic pregnancies in the United States. In a review of risk factors for ectopic pregnancy in over 94,000 pregnancies in the registry,^387^ risks were decreased with donor egg or surrogate pregnancies, consistent with maternal factors contributing to increased risk. In fresh, non-donor IVF/ICSI, risk was increased with histories of tubal disease, endometriosis, or other female cause of infertility after adjustment for other risk factors. Risks with fresh versus frozen transfer, IVF versus ICSI, or with assisted hatching, were not different after adjustment. Interestingly, risks were significantly decreased if one or two embryos with good quality scores were transferred, but not with three or more, suggesting that at least some of the contribution to increased ectopic rates is attributable simply to increasing the mathematical probability of implantation. In another registry study comparing outcomes of women with intrauterine pregnancies alone with heterotopic pregnancies, spontaneous abortion of the intrauterine gestation in heterotopic pregnancies was significantly more likely (RR 2.05; 95 percent CI 1.67–2.51), with the subsequent probability of livebirth significantly reduced (RR 0.70; 0.62–0.79). Risks for low birth weight and preterm delivery were also increased, but not significantly.

2. Other systematic reviews. We did not identify any other systematic reviews on this topic.

3. Conclusions. Although ectopic pregnancy is more common after assisted reproduction than after spontaneous conception, and variations are observed between different methods of ART, most of the difference in risk appears to be related to factors related to the mother and/or embryo rather than specific procedures. There is good evidence discussed earlier that removal of hydrosalpinges prior to undergoing ART reduces the ectopic risk.

C. Maternal serum screening for chromosomal abnormalities. Discussion of options for screening for fetal chromosomal abnormalities, including Down's syndrome, is recommended for all pregnant women.^392^ Currently, both first and second trimester screening tests are available; the optimal choice of either or both is based on the availability of the specific tests, the availability of first-trimester chromosomal evaluation using chorionic villus sampling (CVS), and patient preferences. Studies of second trimester serum tests suggested that the false positive rate of testing was higher in women who were pregnant after assisted reproduction; this was clinically relevant not only because of the risk of fetal loss after CVS or amniocentesis for definitive diagnosis, but there was some evidence that women with false positive results were more likely to experience later adverse pregnancy outcomes.^393,394^

1. Included studies. Table 50 shows included studies with estimates of the relative risk (with 95 percent CIs) for false positive results.

Table 50 Maternal screening for fetal chromosomal abnormalities

Study | Exposure | | N | Measure of Association
RR/OR | Lower 95% CI | Upper 95% CI
Abnormal nuchal translucency
Hui et al., 2005^395^ | Reference | Spontaneous | 16773
Hui et al., 2005^395^ | | ART | 301 | 2.00 | 1.42 | 2.81
| Cohort, singletons
First trimester serum screening
Lambert-Messerlian et al., 2006^397^ | Reference | Spontaneous | 37070
Lambert-Messerlian et al., 2006^397^ | | Any infertility treatment | 962
| Cohort, FASTER trial | | 95 % CI of observed screen positive rates included expected rate based on known maternal factors (gestational age, maternal race, diabetes, weight)
Wojdemann et al., 2001^398^ | Reference | Spontaneous | 3029
Wojdemann et al., 2001^398^ | | IVF | 47 | 0.87 | 0.22 | 3.41
Wojdemann et al., 2001^398^ | | Ovulation induction | 63 | 0.97 | 0.32 | 2.97
| Cohort, screen positive results; 1^st^ trimester
Orlandi et al., 2002^399^ | Reference | Spontaneous | 363
| ART | 66 | 1.75 | 0.78 | 3.93
Second trimester serum screening
Rice et al., 2005^400^ | Reference | Spontaneous | 596
Rice et al., 2005^400^ | | IVF | 88 | 1.25 | 0.76 | 2.07
| Cohort
Muller et al., 2003^401^ | Reference | Spontaneous | 21014
Muller et al., 2003^401^ | | ART | 1515 | 1.44 | 1.25 | 1.66
| Cohort | | Risks 1.01–1.15, with CIs crossing 1.0 when stratified by maternal age
Lambert-Messerlian et al., 2006^397^ | Reference | Spontaneous | 37070
Lambert-Messerlian et al., 2006^397^ | | Any infertility treatment | 962
| Cohort, FASTER trial | | Observed screen positive rate significantly higher for all groups except embryo donors (but total n for this subgroup only 115) after adjusted for gestational age, maternal race, diabetes, weight
1^st^ and 2^nd^ trimester combined
Tul and Novak-Antolic, 2006^402^ | Reference | Spontaneous | 914
Tul and Novak-Antolic, 2006^402^ | | IVF | 130 | 3.01 | 1.57 | 5.78
Tul and Novak-Antolic, 2006^402^ | | ICSI | 54 | 4.23 | 1.94 | 9.24
| Cohort, any positive result | | Adjusted for maternal age: IVF: 1.67 (0.79, 3.54); ICSI: 2.78 (1.1, 7.0)
Maymon and Shulman, 2002^394^ | Reference | Spontaneous | 285
Maymon and Shulman, 2002^394^ | | IVF | 71 | 1.00 | 0.11 | 8.84
| Cohort, singletons, 1998-1999; 1^st^ and 2^nd^ trimester | | Risk increased for 2^nd^ trimester screening, but CIs cross 1.0
Maymon and Shulman, 2004^396^ | Reference | Spontaneous | 1781
Maymon and Shulman, 2004^396^ | | IVF | 99 | 1.64 | 0.73 | 3.68
| Cohort, singletons, 2000-2002; 1^st^ and 2^nd^ trimester | | Risk increased for both, significant only for nuchal translucency and PAPP-A

Two studies that explicitly reported results for nuchal translucency found increased risks of false positives,^395,396^ although this was not observed in a larger, prospective trial.^397^ Risks for first trimester serum screening were not significantly increased in three studies, including one with over 38,000 subjects;^397^–^399^ however, second trimester false positive screening results were consistently elevated in four studies,^394,^,^397,^,^400,401^ including studies with over 21,000^401^ and 38,000 subjects.^397^ Of note, in the largest study, the FASTER trial, increased risks were seen with both IVF/ICSI and ovulation stimulation treatments.^397^ A particular strength of this study was the validation of exposure. The combination of elevated risk with nuchal translucency and elevated second trimester serum tests led to an overall increased false positive rate with combined screening in the two largest, most recent studies.^396,402^

Two studies provided evidence that some of this observed increase in false positive risk is due to confounding by maternal age;^401,402^ adjustment for maternal age resulted in substantial reductions in the risk estimate.

Three studies that explicitly compared results between IVF and spontaneous twins found either a reduced^403^ or similar risks for false positive results with nuchal translucency,^404^ or similar results for second trimester alpha-fetoprotein.^405^

2. Other systematic reviews. We did not identify any published systematic reviews on this topic.

3. Conclusions. The best available evidence suggests that false positive results for maternal testing for chromosomal abnormalities after ART are more likely for second trimester serum screening, resulting in an increased false positive rate with combined screening strategies. The evidence for first trimester screening is more equivocal, with the largest prospective study showing no difference for nuchal translucency. Some of this increased risk appears to be due to differences in the distribution of maternal age. These results are biologically plausible, especially for second trimester serum screening, where most tests are based on measurement of placental proteins. Abnormal implantation in these patients, or placental abnormalities resulting from spontaneous or purposeful fetal reduction in the setting of multiple pregnancies, may lead to subsequent abnormal levels of these markers. Further research is needed to determine whether adjustment of thresholds for referral for invasive testing in patients pregnant after infertility treatment is needed. In addition, because false positive test results in a general population have been associated in some studies with an increased risk for later pregnancy complications which are also increased in infertility patients, additional research into the potential clinical utility of these results is also needed.

D. Preterm delivery - singletons. This section examines the evidence concerning preterm delivery in singletons.

1. Included studies. Identified studies meeting our inclusion criteria are shown in Table 51. Consistently, women pregnant after IVF/ICSI had a 70 to 150 percent increase in the likelihood of delivery prior to 37 weeks. However, we did not identify any data to help estimate what proportion of these births were early deliveries due to maternal or fetal complications which are more common in these patients, such as preeclampsia (see below), versus preterm delivery secondary to spontaneous preterm labor without an identifying underlying cause. Of note, the one study we identified that was restricted to patients pregnant after superovulation found a similar risk increase.

Table 51 Preterm delivery in singletons

Study | Exposure | | N | Measure of Association
RR/OR | Lower 95% CI | Upper 95% CI
IVF/ICSI vs. spontaneous
Koudstaal et al., 2000^406^ | Reference | Spontaneous | 307
Koudstaal et al., 2000^406^ | | IVF | 307 | 2.56 | 1.52 | 4.30
| Cohort, matched controls
Perri et al. 2001^407^ | Reference | Spontaneous | 2546
Perri et al. 2001^407^ | | IVF | 95 | 2.75 | 1.80 | 4.21
| Cohort | | Preterm birth < 37 wk. Risk estimate increased to (4.75, 95% CI 2.16, 10.45) with only matched controls.
Poikkeus et al., 2006^408^ | Reference | Spontaneous | 304
Poikkeus et al., 2006^408^ | | IVF/ICSI | 324 | 2.19 | 1.02 | 4.70
| | | Preterm birth < 37 wk
Klemetti et al., 2002^409^ | Reference | Spontaneous | 111,516
Klemetti et al., 2002^409^ | | IVF | 1893 | 1.79 | 1.52 | 2.11
| | | Preterm birth < 37 wk. Controlled for county, smoking, maternal age, parity, and gravidity.
Wang et al., 2002^410^ | Reference | Spontaneous | 660
Wang et al., 2002^410^ | | IUI (minimal stimulation) | 567 | 1.24 | 0.79 | 1.97
| IVF/GIFT | 569 | 2.33 | 1.55 | 3.52
Single embryo transfer
De Neubourg et al., 2006^411^ | Reference | Spontaneous | 59,535
De Neubourg et al., 2006^411^ | | Single embryo transfer | 251 | 1.62 | 1.11 | 2.35
| Cohort | | Preterm birth < 32 wk: 1.01 (0.25, 4.04)
De Sutter et al., 2006^412^ | Reference | Single embryo transfer | 404
De Sutter et al., 2006^412^ | | Double embryo transfer | 431 | 1.69 | 1.05 | 2.70
| Cohort, singletons only | | Preterm birth < 37 wk
Poikkeus et al., 2007^413^ | Reference | Spontaneous | 15037
Poikkeus et al., 2007^413^ | | Single embryo transfer | 269 | 2.77 | 2.00 | 3.85
Poikkeus et al., 2007^413^ | | Double embryo transfer with single ongoing pregnancy | 230 | 2.55 | 1.76 | 3.69
| Cohort | | Preterm birth < 37 weeks; risk remained unchanged after adjustment for maternal age, parity, and socioeconomic status
IVF vs. ICSI
Rajesh et al., 2006^414^ | Reference | IVF only | 53
Rajesh et al., 2006^414^ | | IVF + ICSI | 103 | 3.09 | 0.95 | 10.0
| Cohort | | Preterm birth < 37 wk
Bonduelle et al., 2002^415^ | Reference | IVF | 1393
Bonduelle et al., 2002^415^ | | ICSI | 1300 | 0.96 | 0.77 | 1.21
| Not entirely contemporaneous - IVF 1983-1999, ICSI 1991-1999 | | Preterm birth < 37 wk
Superovulation vs. spontaneous
Ombelet et al., 2006^416^ | Reference | Spontaneous | 12,021
Ombelet et al., 2006^416^ | | Ovulation induction | 12,021 | 1.82 | 1.64 | 2.03
| Cohort, matched controls | | Preterm birth < 37 wk

2. Other systematic reviews. Four systematic reviews consistently found an increased risk of preterm birth among singleton infants following IVF, with odds ratios for birth prior to 37 weeks of 1.98 (1.89–2.08);^417^ 1.95 (1.73–2.20);^418^ 2.04 (1.80–2.37; with risk for delivery prior to 32 weeks OR 3.22; 95 percent CI 2.03–5.08);^372^ and 1.93 (1.36–2.20; with risk for delivery before 33 weeks OR 2.99; 95 percent CI 1.54–5.80).^419^ Given that there was considerable overlap in the included studies, the consistency of the risk estimate is not surprising.

3. Conclusions. Preterm delivery is approximately twice as likely in women pregnant after infertility treatment compared to spontaneous pregnancies. The evidence is most consistent for IVF/ICSI, but the risk was similar in a large study of women pregnant after ovulation induction alone. The proportion of these deliveries that are due to early delivery indicated by maternal or fetal complications versus idiopathic fetal delivery is unclear. To date, strategies to prevent idiopathic preterm birth have proven ineffective, although there is recent evidence that progesterone may be effective in some high-risk patients (those with a history of preterm birth or a cervix less than 15 mm on ultrasound).^420^ If a significant proportion of these preterm deliveries are idiopathic, a trial of progesterone in women pregnant after ART should be considered; given the use of progesterone for luteal support, this trial would involve testing whether the continuation of progesterone into the second and third trimesters reduced the incidence of preterm delivery.

E. Preterm delivery - multiples. All multiple gestations are at increased risk for preterm delivery compared to singleton pregnancies, with the average age of delivery decreasing with each additional fetus.^421^ However, from both a clinical and scientific viewpoint, the question of whether infertility treatment increases the risk for preterm delivery in multiple gestations compared to spontaneous multiples is of great interest.

1. Included studies. Included studies are summarized in Table 52. Although ART twins are more likely to deliver prior to 37 weeks than spontaneous twins, this increased risk is much smaller than that observed for ART singletons compared to spontaneous singletons. The point estimates for increased risk are consistently much smaller than observed with singletons. Even in a study that included higher order multiples, the point estimate for preterm birth risk was substantially lower for IVF multiples, most of which were twins, compared to IVF singletons.^409^ In a cohort of twins resulting from selective reduction of higher order multiple gestation, risk of preterm delivery was significantly increased compared to twin gestations resulting from ART that did not start as higher order multiples.^422^

Table 52 Preterm delivery in twins

Study | Exposure | | N | Measure of Association
RR/OR | Lower 95% CI | Upper 95% CI
IVF/ICSI vs. spontaneous twins
Choi et al., 2006^423^ | Di-chorionic twins | Spontaneous | 156
Choi et al., 2006^423^ | | IVF | 193 | 1.35 | 0.95 | 1.90
Choi et al., 2006^423^ | Monochorionic twins | Spontaneous | 154
Choi et al., 2006^423^ | | IVF | 34 | 1.22 | 0.68 | 2.21
| Cohort | | Preterm birth < 34 wk
Huang et al., 2006^424^ | Reference | Spontaneous | 50
Huang et al., 2006^424^ | | IUI | 63 | 0.91 | 0.57 | 1.46
Huang et al., 2006^424^ | | IVF/ICSI | 81 | 1.08 | 0.71 | 1.65
| Cohort | | Preterm < 37 wk. Similar for birth < 32 wk; unclear if IUI in paper includes superovulation
Klemetti et al., 2002^409^ | Reference | Spontaneous | 1396
Klemetti et al., 2002^409^ | | IVF | 515 | 1.43 | 1.13 | 1.80
| Includes higher order multiples | | Preterm birth < 37 wk
Koudstaal et al., 2000^426^ | Reference | Spontaneous | 96
Koudstaal et al., 2000^426^ | | IVF | 96 | 1.46 | 0.83 | 2.58
| Cohort | | Preterm birth < 37 wk
Manoura et al., 2004^427^ | Reference | Spontaneous | 148
Manoura et al., 2004^427^ | | IVF | 73 | 1.23 | 1.02 | 1.47
| Cohort | | Preterm birth < 37 wk
Nassar et al., 2003^428^ | Reference | Spontaneous | 112
Nassar et al., 2003^428^ | | IVF | 56 | 3.03 | 1.54 | 5.95
| Cohort | | Preterm birth < 37 wk
Pinborg et al., 2004^429^ | Reference | Spontaneous | 10239
Pinborg et al., 2004^429^ | | IVF | 3393 | 1.04 | 0.99 | 1.09
| Cohort | | Preterm birth < 37 wk
Pinborg et al., 2004^430^ | Reference | Spontaneous | 1496
Pinborg et al., 2004^430^ | | IVF | 538 | 1.22 | 1.01 | 1.47
| Cohort | | Preterm birth < 37 wk
Putterman et al., 2003^425^ | Reference | Spontaneous | 101
Putterman et al., 2003^425^ | | Ovulation induction | 34 | 0.97 | 0.71 | 1.34
Putterman et al., 2003^425^ | | IVF | 60 | 0.88 | 0.66 | 1.17
| Cohort | | Preterm birth < 37 wk. Similar results for birth < 32 wk
Saygan-Karamursel et al., 2006^431^ | Reference | Spontaneous | 348
Saygan-Karamursel et al., 2006^431^ | | ICSI | 274 | 1.20 | 1.08 | 1.32
| Cohort | | Preterm birth < 37 wk
Verstraelen et al., 2005^432^ | Reference | Spontaneous | 2915
Verstraelen et al., 2005^432^ | | Superovulation | 710 | 1.20 | 1.11 | 1.30
Verstraelen et al., 2005^432^ | | IVF/ICSI | 743 | 0.96 | 0.90 | 1.03
| Cohort | | Preterm birth < 37 wk
Zuppa et al., 2001^433^ | Reference | Spontaneous | 228
Zuppa et al., 2001^433^ | | ART | 32 | 1.43 | 1.13 | 1.80
| Cohort
Ovulation induction vs. spontaneous
Ombelet et al., 2006^416^ | Reference | Spontaneous | 3108
Ombelet et al., 2006^416^ | | Superovulation | 3108 | 1.04 | 0.99 | 1.09
| | | Preterm birth < 37 wk
ART twins reduced from higher order multiples vs. ART twins that were not reduced
Cheang et al., 2007^422^ | Reference | Non-reduced ART twins | 389
Cheang et al., 2007^422^ | | Reduced ART twins | 353 | 1.24 | 1.03 | 1.50
| Cohort | | Risk for delivery prior to 28 weeks 2.52 (1.05, 6.05)

Because twins from spontaneous conceptions deliver earlier as well, some of this difference may simply reflect a larger proportion of spontaneous pregnancies delivered before 37 weeks; however, those studies that also reported preterm birth using earlier thresholds^423^–^425^ had similar findings.

2. Other systematic reviews. Two systematic reviews reported similar findings. The first, which also included a review of outcomes of singleton pregnancies, found that the relative risk for preterm birth in ART twins compared to spontaneous twins was substantially lower than the relative risk for preterm birth in ART singletons compared to spontaneous singletons, with summary relative risks of 1.07 (95 percent CI 1.02–1.13) for delivery prior to 37 weeks, and 0.95 (0.78–1.15) for delivery prior to 32 weeks.^372^ The second study found an increased risk for delivery for ART twins compared to spontaneous twins between 32 and 36 weeks in studies matched for maternal age (OR 1.48; 95 percent CI 1.05–2.10), and increased risk of delivery prior to 37 weeks when parity was also matched;^419^ however, these relative risk estimates were still lower than the relative risks observed for singletons. These findings are not necessarily contradictory, given differences in study inclusion criteria, analytic methods, and the potential impact of different definitions of preterm birth. The most striking finding is the within-study finding of Helmerhorst and colleagues that the summary risk, using identical methods and study selection criteria, is so much lower for twins than for singletons.^372^

3. Conclusions. Twins resulting from either ART or spontaneous conceptions are more likely to deliver prior to 37 weeks than singleton ART or spontaneous conceptions, and both twins and singletons resulting from ART are more likely to deliver prior to term than twins and singletons born after spontaneous conception. However, the evidence is fairly consistent that the relative increase in preterm delivery risk associated with ART is substantially higher for singletons than for twins. This may be due to a higher proportion of spontaneous twins being born below a given gestational age threshold. It is also consistent with the hypothesis that, given multiple embryo transfer, twin pregnancies are more likely in the setting of maternal and/or embryonic features which confer a better chance of establishing a successful pregnancy. However, from a clinical and public health perspective, the fact that twins overall are more likely to deliver prior to term compared to singletons means that, even with a smaller increase in relative risk, the absolute number (or attributable risk ) of preterm twins associated with ART will be substantial.

F. Low birth weight - singletons. Given that weight at birth increases with increasing gestational age, one would expect low birth weight (defined as less than 2500 g) or very low birth weight (less than 1500 g) to be more common in a group more likely to have preterm delivery. The more interesting question is whether, for a given gestational age, infants born after infertility treatment are smaller than infants born after spontaneous conception.

1. Included studies. In general, all of the studies cited above that reported an increased risk of preterm delivery also reported increased risks of low birth weight and very low birth weight. However, only a few provided data on gestational age-specific relative weights, most often expressed as the proportion below the 10^th^ percentile (“small for gestational age,” or SGA), adjusted for the appropriate population. A Finnish study^434^ did not detect a difference in SGA in 118 singleton pregnancies after IVF in women with unexplained infertility compared to either an age- and parity-matched group of women with spontaneous pregnancies or women with other diagnoses. However, in a Dutch study of 307 ART pregnancies and 307 controls matched for known risk factors for preterm birth and low birth weight, the risk of SGA was considerably increased (RR 2.08; 95 percent CI 1.21–3.70).^406^ A Danish population-based study found a similarly elevated risk (RR 1.38; 1.22–1.56).^435^ Similarly, data from the SART registry in the United States found that the standardized risk ratio for term low birth weight among ART infants was significantly elevated (RR 2.6; 2.4–2.7), and substantially higher than the risk observed with preterm infants (RR 1.4; 1.3–1.5).^436^

Two other studies provide evidence suggesting a role for implantation and placentation in this increased risk. A large (more than 60,000 subjects) population-based Danish study^437^ found similarly increased risks for SGA in singleton pregnancies both in women treated for infertility (RR 1.40; 1.23–1.60) and in women spontaneously conceiving after more than 12 months of attempting pregnancy (RR 1.24; 1.10–1.40), consistent with an underlying maternal and/or embryonic cause. Risks were also elevated for ART singletons that originally started with more than one gestation (“vanishing twins”) compared to ART pregnancies that started as singletons (RR 1.48; 1.03–2.11).^438^

2. Other systematic reviews. The three relevant systematic reviews all found significantly increased risks of low birth weight and very low birth weight among singletons born after assisted reproduction. Where SGA was reported, all three reviews also reported consistently elevated risks for SGA: 1.59 (95 percent CI 1.20–2.11);^419^ 1.60 (1.25–2.04);^418^ and 1.40 (1.15–1.71).^372^

3. Conclusions. In addition to the expected increased risk of low and very low birth weight associated with an increased rate of preterm birth, singleton infants born after infertility after in vitro fertilization are more likely to be in the lowest percentiles of birth weight for a given gestational age than infants born after spontaneous conception. Since intrauterine growth is strongly dependent on placental function, this observation is consistent with an increase in abnormalities of implantation/placentation in IVF pregnancies. Again, the extent to which this is a function of treatments, maternal/embryonic factors, or both is unclear from the available evidence, although studies demonstrating increased risks in subfertile women who spontaneously conceive, and in singleton “survivors” after loss of a twin suggest a strong contribution from maternal/embryonic factors.

G. Low birth weight-multiples. At any given gestational age, birth weight will decrease as the number of fetuses increase, and thus twins are more likely to be classified as low or very low birth weight. Again, the main clinical and scientific question of interest is whether gestational age-specific weights for multiples born after infertility treatment are less than those for multiples born after spontaneous conception.

1. Included studies. As was seen in the review of preterm birth, the reported relative risk of low or very low birth weight in multiples born after infertility treatment (mostly twins) compared to spontaneous multiples was lower, with confidence intervals including unity, at least partly because the preterm birth risk difference was lower. Three of the included studies^426,^,^434,435^ did not detect a difference in the rates of SGA among assisted reproduction and spontaneous twins, while one^439^ demonstrated a significantly lower risk for IVF twins compared to spontaneous twins (RR 0.78; 95 percent CI 0.64–0.94), and similar risks for twins after ovulation induction compared to spontaneous twins (RR 0.99; 0.83–1.19).

2. Other systematic reviews. The relative risks of low birth weight and SGA were not significantly different between IVF and spontaneous twins in the two relevant systematic reviews.^372,419^ No data were available for higher order multiple gestations; given the small numbers of spontaneous higher order multiples, estimates of risk would likely be quite imprecise.

3. Conclusions. The available evidence suggests that there is not an increased risk for low and very low birth weight among ART twins compared to spontaneous twins, in contrast to the observed relationship between ART and spontaneous singletons. Likewise, the relative distribution of gestational age-specific weights also appears to be similar.

### V. Maternal Outcomes during Pregnancy

Implantation of the embryo appears to be one of the most critical steps in establishing a normal pregnancy in both natural and assisted reproduction. Early pregnancy loss occurs in 25 to 30 percent of conceptions,^373^ and although chromosomal abnormalities are the most common single etiology,^440^ relatively small variations in the complex process may affect the likelihood of a successful pregnancy.^441^ Implantation is the biggest remaining barrier to improving pregnancy rates in assisted reproduction.^442,443^

Implantation appears to play a key role in the etiology of many complications of pregnancy, including preeclampsia, abnormalities of fetal growth, and placental abnormalities such as placenta previa and abruption.^444,445^ Given the association between assisted reproduction and disorders of fetal growth noted above, an increased risk of maternal complications associated with implantation is biologically plausible.

A. Preeclampsia. Preeclampsia, a disorder manifested by hypertension and proteinuria, which can lead to significant maternal and fetal morbidity and mortality, commonly occurs in women with several characteristics that are frequently seen in women who become pregnant after infertility treatment, including first pregnancies, maternal age greater than 35, multiple gestation, and obesity.^446^

1. Included studies. Identified studies meeting inclusion criteria are summarized in Table 53. As seen there, the risk of preeclampsia was consistently elevated in women after assisted reproduction with IVF and ICSI. Of interest, although there was a non-significant trend for increasing risk with increasing BMI in one cohort,^447^ and a decrease in the point estimate of the risk after adjustment for pre-pregnancy BMI in another,^439^ obesity alone cannot explain the risk. The group at theoretically highest risk would be women with PCOS, since obesity is a common feature of the syndrome, yet ovulation or superovulation with clomiphene or gonadotropins, the two treatments most likely to be used in PCOS, had smaller risk estimates than IVF, with confidence intervals that crossed 1.0, in two studies that included patients who had received both types of treatments.^448,449^ In all the studies involving singleton pregnancies, risks remained significantly elevated after adjustment for potential confounders such as maternal age and parity. In two of the three studies of multiple gestations,^430,^,^431,448^ risks also remained significantly elevated after adjustment

Table 53 Preeclampsia in pregnancies after infertility treatment

Study | Exposure | | N | Measure of Association
RR/OR | Lower 95% CI | Upper 95% CI
IVF
Dokras et al., 2006^447^ | Study Type | Cohort; n = 1293, fresh IVF cycles | | Trend for increased risk for preeclampsia with increasing BMI, but insufficient power except when comparing BMI < 25 to BMI ≥ 40
Erez et al., 2006^450^ | | Controls | 2336
Erez et al., 2006^450^ | | Cases | 292 | 2.35 | 1.68 | 3.29
Study type | Case-control | | OR adjusted for chronic HTN, diabetes, primiparity, twin discordance, and maternal age, 1.08 (0.74, 1.39)
Ochsenkuhn, et al., 2003^451^ | Reference | Spontaneous*
Ochsenkuhn, et al., 2003^451^ | | IVF/GIFT* | | 3.65 | 1.02 | 13.0
Ochsenkuhn, et al., 2003^451^ | Study type | Cohort (includes GIFT); n = 400 *Singletons
Tabs et al., 2004^452^ | Reference | Spontaneous
Tabs et al., 2004^452^ | | IVF | | 5.16 | 1.67 | 15.9
Study type | Cohort; n = 39,256; singletons | | Eclampsia risk 12.3 (1.68, 90.9); not adjusted for maternal age or parity
ICSI
Saygan-Karamursel et al., 2006^431^ | | Spontaneous
Saygan-Karamursel et al., 2006^431^ | | ICSI | | 2.79 | 1.35 | 5.80
Study type | Cohort, n = 622; twins | | Adjusted for maternal age 2.14 (0.91, 5.02)
Ovulation induction/superovulation and IVF/ICSI
Lynch et al., 2002^448^ | Reference | Spontaneous
Lynch et al., 2002^448^ | | Clomiphene | | 1.79 | 0.97 | 3.30
Lynch et al., 2002^448^ | | Gonadotropins | | 2.25 | 0.99 | 5.10
Lynch et al., 2002^448^ | | IVF/ICSI | | 4.66 | 2.59 | 8.37
Lynch et al., 2002^448^ | Study type | Cohort; n = 528; all multiple gestations | | Only IVF/ICSI significantly associated after adjustment for maternal age (OR 2.8; 1.7–7.0)
Lynch et al., 2002^448^ | Reference | Spontaneous
Lynch et al., 2002^448^ | | Ovulation induction | | 1.37 | 0.52 | 3.59
Lynch et al., 2002^448^ | | IVF | | 1.96 | 1.34 | 2.86
Study type | Cohort; n = 36,062; singletons
Any ART
Pinborg et al., 2004^430^ | | Cohort: n = 1436; twins | | OR adjusted for maternal age and parity: 1.0 (0.5, 1.7) (crude RR not reported)
Kozinszky et al., 2003^453^ | Reference | Spontaneous
Kozinszky et al., 2003^453^ | | ART | | 1.67 | 1.09 | 2.54
| Cohort; n = 777; singletons | | Matched for age and parity
Any infertility treatment
Hernandez-Diaz et al., 2007^454^ | Reference | Spontaneous
Hernandez-Diaz et al., 2007^454^ | | Any infertility | | 1.77 | 1.37 | 2.30
Study type | Cohort, n = 5151 | | Risk decreased after adjustment for prepregnany BMI, parity, multiple gestation (1.30; 1.00, 1.90). Both history of infertility and diagnosis of gestational hypertension based on subject self-report.

There were no data to allow any assessment about the degree to which the association between infertility treatment, particularly IVF/ICSI, is related to the treatment (abnormal implantation leading to a greater likelihood of preeclampsia) or the underlying condition (factors associated with abnormal implantation that contribute to both infertility and preeclampsia). One line of evidence that would support the underlying condition hypothesis would be data showing an increased risk among women with unexplained infertility compared to women with other causes, especially women with normal ovarian and endometrial function, such as those with tubal infertility.

2. Other systematic reviews. In the meta-analysis of Jackson and colleagues,^418^ the risk for preeclampsia among singleton pregnancies after IVF was significantly elevated (OR 1.55; 95 percent CI 1.23–1.95).

3. Conclusions. The risk of preeclampsia is consistently elevated in women undergoing infertility compared to women with spontaneous pregnancies, even after adjustment for common risk factors. Several studies suggest that the risk is higher for women undergoing IVF/ICSI compared to women treated with ovulation induction or superovulation. The extent to which this association is due to the underlying etiology of infertility versus the treatment is unclear.

B. Other complications/outcomes. Other complications/outcomes reported included gestational diabetes, placental abnormalities, and psychological outcomes.

1. Included studies. Gestational diabetes is also associated with risk factors common in infertility patients; in particular, as discussed above, anovulation is often associated with insulin resistance prior to pregnancy. The studies we identified (Table 54) did not provide consistent evidence for an increased risk.

Table 54 Gestational diabetes in pregnancies after infertility treatment

Study | Exposure | | N | Measure of Association
RR/OR | Lower 95% CI | Upper 95% CI
IVF
Dokras, et al., 2006^447^ | Study type | Cohort; n = 1293, fresh IVF cycles | | Trend for increased risk for gestational diabetes with increasing BMI, but insufficient power except when comparing BMI < 25 to BMI ≥ 40
Pinborg et al., 2004^430^ | Study type | Cohort | | OR adjusted for maternal age and parity: 1.9 (0.9,4.0) (crude RR not reported)
ICSI
Saygan-Karamursel et al., 2006^431^ | Reference | Spontaneous
Study type | Cohort, n = 622; twins | | Adjusted for maternal age: 3.22 (1.17, 8.85)
Gonadotropins
Vollenhoven, et al., 2000^455^ | Reference | Spontaneous
Vollenhoven, et al., 2000^455^
| PCOS with Gonadotropins | | 1.29 | 0.62 | 2.70
Study type | Cohort; n = 120
Ovulation induction and IVF/ICSI
Shevell et al., 2005^449^ | Reference | Spontaneous
Shevell et al., 2005^449^ | | Ovulation induction | | 1.69 | 0.82 | 3.47
Shevell et al., 2005^449^ | | IVF | | 0.80 | 0.48 | 1.32
Study type | Cohort; n = 36,062; singletons

However, there was very strong and consistent evidence of an association between assisted reproduction and placental abnormalities such as placenta previa or placental abruption in two large cohort studies (Table 55).

Table 55 Placental abnormalities in pregnancies after infertility treatment

Study | Exposure | | N | Measure of Association
RR/OR | Lower 95% CI | Upper 95% CI
IVF or ICSI
Romundstad, et al., 2006^456^ | Reference | Spontaneous singletons
Romundstad, et al., 2006^456^ | | ART singletons | | 7.24 | 5.86 | 8.94
Romundstad, et al., 2006^456^ | | Spontaneous twins
Romundstad, et al., 2006^456^ | | ART twins | | 3.82 | 2.02 | 7.21
Study type | Cohort; n = 502,840 | | Placenta previa — Adjusted for maternal age, parity, previous C-section, duration between births, year of birth: singletons 5.5 (4.4, 7.0); twins 2.9 (1.5, 5.8). Risk also increased in women with both spontaneous and ART conceptions.
Ovulation induction and IVF
Shevell et al., 2005^449^ | Reference | Spontaneous
Shevell et al., 2005^449^ | | Ovulation induction | | 1.36 | 0.19 | 9.65
Shevell et al., 2005^449^ | | IVF | | 3.61 | 2.03 | 6.41
Study type | Cohort; n = 36,062 | | Placental abruption — ovulation 2.34 (0.59, 9.31), IVF 3.09 (1.74, 5.49)

Finally, we identified three Scandinavian studies that addressed psychological outcomes using standardized, validated instruments during pregnancy. In a cohort of 112 nulliparous women and 82 male partners assessed during the first trimester, women in the IVF group reported significantly more muscular tension and irritability, while men in the IVF group reported more somatic and psychic anxiety, detachment, indirect aggression, and guilt.^457^ In another study of 216 subjects, overall scores on a standardized marital function scale were high in both IVF and spontaneous conception parents, with IVF parents being consistently higher on 6 of 10 subscales; scores declined at 12 months postpartum for the control group but remained high in the IVF group.^458^ A Finnish cohort using validated pregnancy-specific scales found no difference in pregnancy-related anxiety (RR for severe anxiety 1.23; 95 percent CI 0.83–1.86) or fear of childbirth (severe fear RR 1.08; 95 percent CI 0.72–1.63) when comparing nulliparous women after spontaneous or assisted conception.^459^

2. Other systematic reviews. Gestational diabetes was significantly increased in the review of Jackson and colleagues (OR 2.00; 95 percent CI 1.36, 2.99).^418^ Risks were also substantially higher for preeclampsia (OR 1.55; 1.23–1.95) and placenta previa (OR 2.87; 1.54–5.37).

3. Conclusions. The risk of pregnancy complications associated with implantation - preeclampsia, placenta previa, and placental abruption - is consistently elevated in the studies we identified. This increased risk is biologically plausible, but it is unclear if this association is because of the underlying etiology or the treatment itself. Further insight into this question could be gained through properly designed and adequately powered studies that compare the incidence of these conditions between infertile women with tubal infertility only versus women with other conditions, especially unexplained infertility. Data on the risk of gestational diabetes are less consistent. Finally, the limited available data suggest that psychological outcomes during pregnancy for couples undergoing assisted reproduction are similar, or better than, couples after spontaneous pregnancy. Further studies of this question in other settings, and including fathers, are warranted.

### VI. Infant Outcomes from Birth to 1 Year

A. Congenital anomalies. This section considers reports of congenital anomalies in ART-conceived children from birth to age 1 year.

1. Included studies. Table 56 summarizes studies meeting our inclusion criteria. In general, there is an increased risk of major malformations among infants born after IVF or ICSI which is also seen in those studies that included women receiving other types of infertility treatment. In those studies with sufficient size and data to allow controlling for potential confounders, risks decrease; in the largest population-based study, years of involuntary childlessness was a significant confounder.^460^ There is insufficient evidence to determine whether there is a clear relationship with specific abnormalities, including disorders of imprinting.

Table 56 Congenital anomalies, birth to 1 year, in children conceived through assisted reproduction

Study | Exposure | | N | Measure of Association
RR/OR | Lower 95% CI | Upper 95% CI
All malformations
Anthony et al., 2002^461^ | All malformations | Spontaneous | 314,605
Anthony et al., 2002^461^ | | ART | 4224 | 1.20 | 1.01 | 1.43
Anthony et al., 2002^461^ | | | | 1.03 (0.6–1.23) after adjustment for maternal age, race, parity
Anthony et al., 2002^461^ | Major | Spontaneous | 314,605
Anthony et al., 2002^461^ | | ART | 4224 | 1.23 | 0.84 | 1.79
Anthony et al., 2002^461^ | Minor | Spontaneous | 314,605
Anthony et al., 2002^461^ | | ART | 4224 | 1.17 | 0.89 | 1.53
| Cohort (registry linkage)
Belva et al., 2007^462^ | Major | Spontaneous
Belva et al., 2007^462^ | | ICSI | | 2.94 | 1.10 | 7.88
Belva et al., 2007^462^ | Minor | Spontaneous
Belva et al., 2007^462^ | | ICSI | | 1.42 | 0.89 | 2.25
| Cohort | | 60% response rate, self-report
Bonduelle et al., 2002^415^ | Major | IVF | 2955
| ICSI | 2840 | 0.89 | 0.68 | 1.17
Bonduelle et al., 2004^463^ | Reference | Spontaneous | 266
| ICSI | 300 | 2.30 | 1.00 | 5.32
Bonduelle et al., 2005^464^ | Reference | Spontaneous | 538
Bonduelle et al., 2005^464^ | | IVF | 437 | 2.85 | 1.46 | 5.59
| ICSI | 540 | 1.88 | 0.90 | 3.95
Zhu et al., 2006^465^ | Any ICD-10 malformation | Spontaneous, ≤ 12 months | 50,870
Zhu et al., 2006^465^ | | Spontaneous, > 12 months | 5764 | 1.20 | 1.07 | 1.35
Zhu et al., 2006^465^ | | Infertility treatment | 4588 | 1.39 | 1.23 | 1.57
| | | Adjusted for maternal age at conception, prepregnancy BMI, smoking, alcohol intake, coffee consumption, and occupational status. OR increased with time to pregnancy. Genital malformations only subgroup significantly elevated.
Zadori et al., 2003^466^ | Singleton | Spontaneous | 188
Zadori et al., 2003^466^ | | IVF | 188 | 4.07 | 0.45 | 36.72
Zadori et al., 2003^466^ | Twin | Spontaneous | 174
Zadori et al., 2003^466^ | | IVF | 174 | 0.49 | 0.04 | 5.56
| | | Controls matched for maternal age, parity, gravidity
El Hage et al., 2006^467^ | | Spontaneous | 2168
El Hage et al., 2006^467^ | | IVF | 780 | 2.30 | 1.26 | 4.19
| | | Matching or adjustment not reported; IVF/ICSI patients significantly older
Hansen et al., 2002^468^ | All | Spontaneous | 4000
Hansen et al., 2002^468^ | | IVF | 837 | 2.25 | 1.69 | 2.98
Hansen et al., 2002^468^ | | ICSi | 301 | 2.16 | 1.40 | 3.32
Hansen et al., 2002^468^ | Singleton | Spontaneous | 3906
Hansen et al., 2002^468^ | | IVF | 527 | 2.39 | 1.72 | 3.33
Hansen et al., 2002^468^ | | ICSI | 186 | 2.44 | 1.47 | 4.07
| | | OR remained approximately 2 after adjusting for maternal age, parity, infant sex, and correlation between siblings
Kallen et al., 2005^460^ | Reference | Spontaneous | 2 million
Kallen et al., 2005^460^ | | IVF/ICSI | 16,280 | 1.27 | 1.18 | 1.36
| | | ORs decrease, CIs include 1 after adjusting for year of birth, maternal age, parity, years of involuntary childlessness, maternal smoking
Katalinic et al., 2004^469^ | Reference | Spontaneous | 8016
| ICSI | 3372 | 1.45 | 1.26 | 1.67
Klemetti et al., 2005^470^ | Reference | Spontaneous | 26,489
Klemetti et al., 2005^470^ | | Non-IVF Rx | 2930 | 1.24 | 1.03 | 1.49
| IVF | 3926 | 1.52 | 1.25 | 1.84
Koivurova et al., 2002^471^ | Reference | Spontaneous
| IVF | | 1.53 | 0.83 | 2.81
Ludwig and Katalinic, 2002^472^ | Reference | Spontaneous | 30,940
| ICSI | 3372 | 1.25 | 1.11 | 1.40
Merlob et al., 2005^473^ | Reference | Spontaneous | 51,576
| ART | 1632 | 1.73 | 1.48 | 2.03
Olson et al., 2005^474^ | | Spontaneous | 8442
Olson et al., 2005^474^ | | IUI | 343 | 1.13 | 0.70 | 1.82
| IVF | 1462 | 1.41 | 1.12 | 1.76
Kuwata et al., 2004^475^ | | Spontaneous | 94
Kuwata et al., 2004^475^ | | Ovulation induction | 113 | 2.3 | 0.7 | 7.3
Kuwata et al., 2004^475^ | | GIFT | 83 | 3.7 | 1.2 | 11.8
Kuwata et al., 2004^475^ | | IVF | 74 | 3.5 | 1.1 | 11.5
| ICSI | 42 | 6.7 | 2.1 | 21.9
Buckett et al., 2007^476^ | | Spontaneous | 350
Buckett et al., 2007^476^ | | In vitro maturation | 55 | 1.27 | 0.51 | 3.18
Buckett et al., 2007^476^ | | IVF | 217 | 1.10 | 0.61 | 1.98
| ICSI | 160 | 1.49 | 0.83 | 2.68
Specific anomalies
Wu et al., 2006^477^ | Neural tube | Controls | 1608
Wu et al., 2006^477^ | | Cases | 18 | Unadjusted ORs: 4.50 (1.45, 13.93) History of infertility treatment: 9.29 (2.95, 29.26) Clomiphene: 9.85 (2.72,35.71) Small number of cases prevents multivariate adjustment
| Case-control
Whiteman et al., 2000^478^ | Neural tube | Unexposed | 694
Whiteman et al., 2000^478^ | | Treated for subfertilty | 694 | 0.93 | 0.45 | 1.95
| Case-control (29 cases)
Kallen and Robert-Gnansia, 2005^479^ | Craniosynostosis | No infertility treatment | 706,450
Kallen and Robert-Gnansia, 2005^479^ | Case-cohort | Any infertility treatment | 22,770 | 1.13 | 0.66 | 1.93
| Case-control | | Only significant exposure 1^st^ trimester exposure to anti-convulsants
Reefhuis et al., 2003^480^ | Craniosynostosis | Controls | 833
Reefhuis et al., 2003^480^ | | Cases | 41 | 2.70 | 1.28 | 5.69
| Case-control | | Risk for clomiphene, IUI similar
Genetic abnormalities
Aboulghar et al., 2001^481^ | Reference | Spontaneous | 430
Aboulghar et al., 2001^481^ | | ICSI | 430 | 30.03 | 1.80 | 501.13
| Abnormal karyotype
Lidegaard et al., 2005^482^ | Imprinting disorders | Spontaneous | 442,349
| ICSI | 6052 | 0.68 | 0.04 | 10.96

2. Other systematic reviews. We identified one relevant systematic review.^483^ Summary odds ratios for IVF/ICSI combined were significantly elevated (OR 1.29; 95% CI 1.01, 1.67), but risks associated with either IVF or ICSI were not.

3. Conclusions. Risks for major congenital anomalies are increased after infertility treatment, but much of this risk appears to be related to maternal and/or paternal characteristics, including a history of subfertility or infertility. Given the relative rarity of specific birth defects, identifying an association between a specific exposure and subsequent risk is difficult.

B. Physical. This section considers adverse physical outcomes in ART-conceived children from birth to age 1 year.

1. Included studies. Ericson and colleagues conducted a population-based study in Sweden involving 9056 children born after IVF and over 1.4 million children born after spontaneous conception or other infertility treatment using linked data from ART and hospitalization registries.^484^ After adjustment for maternal age, smoking, and parity, children born after IVF had an increased risk of hospitalization for any cause (OR 1.84; 95% CI 1.76–1.92). Risks were increased for term infants (OR 1.34; 1.27–1.41), singletons (OR 1.40; 1.32–1.48) and twins (OR 1.17; 1.07–1.27). The risk estimate decreased and became non-significant for term infants when compared to term infants born after other non-ART infertility treatment or spontaneous time to conception greater than 12 months. Hospitalization rates were highest in the first year, but stayed persistently elevated through age 6; rates were also increased with increasing time to conception. For specific diagnoses, adjusted risks were significantly increased for cerebral palsy, epilepsy, any neurologic diagnosis, tumors (although risk for invasive cancer was not increased), asthma, infection, and congenital malformations.

In an Israeli study of 8161 very low birth weight infants (1396 born after IVF, 6765 born after spontaneous conception), there were no significant differences in risk of any adverse outcome after adjustment for maternal age, gestational age, birth weight, SGA, ethnicity, antenatal steroid therapy, maternal hypertension, delivery mode, and resuscitation for singletons (n = 5975, 4.8 percent from IVF pregnancies), twins (n = 1694, 40.4 percent from IVF pregnancies) or triplets (n = 492, 90.0 percent from IVF pregnancies).^485^ However, point estimates for almost every outcome were elevated, and confidence intervals were quite wide. Given the relatively small numbers, especially of spontaneous multiples, it is possible that adjustment for potential confounders, while appropriate, decreased the study's power to detect clinically relevant differences

2. Other systematic reviews. Risks for admission to the neonatal intensive care unit (NICU) and perinatal mortality for IVF singletons were elevated in all of the relevant systematic reviews,^372,^,^418,419^ although it is unclear to what extent this was due to the observed differences in preterm birth and low birth weight. Conversely, differences were not observed between IVF and spontaneous twins.^372,486^

3. Conclusions. In the neonatal period, although there is evidence of an increased risk for adverse outcomes, especially among singletons, it is unclear to what extent this is due to the observed increased preterm delivery rate. Large-scale studies that control for gestational age and birth weight are needed. In later infancy, there is a significantly increased hospitalization rate among children born after IVF/ICSI compared to the general population, but rates are similar when compared to children born to couples with a history of treated and untreated subfertility.

### VII. Childhood Outcomes at 1 Year and Beyond

A. Physical. This section considers the evidence on adverse physical outcomes in ART-conceived children at age 1 year and beyond. We focused our review on large, preferably population-based, studies.

1. Included studies. As noted above, Swedish hospitalization rates through age 6 were significantly increased in IVF/ICSI children compared to the general population, although rates for children born at term were not increased when compared to similar children whose parents had experienced longer time to conception.^484^ In a similar study in Denmark, IVF/ICSI twins has similar hospitalization/surgery rates compared to spontaneous twins, but significantly higher than IVF/ICSI singletons (term and preterm).^487^ Increased risks for surgery by age 5 were also observed in a Belgian study among both IVF and ICSI children.^464^

Three large population-based studies found no evidence of an increase in childhood cancer rates in children conceived through assisted reproduction, including in Denmark (standardized incidence ratio [SIR] 1.14; 95% CI 0.8–1.5),^488^ the Netherlands (SIR 0.99; 0.35–2.8),^489^ and Australia (SIR 1.39; 0.40–4.77).^490^ A case-control study did find an association between acute myelogenous leukemia (AML) in children with Down syndrome and a history of “ever trying more than 12 months to achieve pregnancy” (OR 2.22; 95 percent CI 1.44– 4.33).^491^ However, this risk was not significantly increased for the index pregnancy (OR for trying more than 12 months for the index pregnancy compared to unplanned or conceived in less than 12 months 1.26; 95 percent CI 0.49–3.24).

2. Systematic reviews. We did not identify any other published systematic reviews of long-term outcomes in this age group.

3. Conclusions. Children born after assisted reproduction have an increased risk of hospitalization and surgery compared to general population controls. At least some of this risk is likely related to the underlying condition causing infertility, rather than to the treatment itself. It is also unclear to what extent these hospitalizations are secondary to conditions related to perinatal events, such as preterm delivery, versus an increased risk of conditions with later onset. Although no differences are observed between twins after treatment compared to other twins, twins born after infertility treatment are more likely to require additional hospitalization than singletons with the same history. Finally, there does not appear to be an increased risk of childhood cancers in children of women who received infertility treatments.

B. Neurological and developmental outcomes. The outcomes considered in this section can be divided into two broad categories: (a) those where there is an obvious physical and/or mental component to the outcome, such as cerebral palsy or epilepsy; and (b) more subtle abnormalities in intellectual and emotional development.

1. Included studies. A Danish study of over 83,000 children reported risks for epilepsy were increased in children of women with untreated subfertility (OR 1.38; 95% CI 1.00–1.89), women treated with ovulation induction (OR 1.83; 1.09–3.06), and women treated with IVF/ICSI (OR 1.73; 1.06–2.71).^492^

Data on the relative incidence of cerebral palsy suggests that any increased risk of cerebral palsy in children born after fertility treatment is related to the increased risk of preterm birth described above. In a large Swedish study with over 14,000 subjects,^493^ IVF was associated with an increased risk of cerebral palsy (RR 1.34; 0.95–1.89) and treatment at a childhood disability center (RR 1.70; 1.30–2.21). However, when stratified by plurality, the increased risk for cerebral palsy was seen only with IVF singletons compared to spontaneous singletons (RR 2.74; 1.29–5.86), but not with IVF twins compared to spontaneous twins (RR 1.07; 0.57–2.00). This is strikingly similar to the results described above for preterm birth and SGA. Another Swedish study found an increased risk for cerebral palsy among IVF singletons, especially if the pregnancy had started as a higher order gestation;^494^ risk for cerebral palsy in IVF singletons was also confounded by SGA and prematurity.^435^ A Danish population-based study^495^ found no difference in the incidence of neurological sequelae, including cerebral palsy, or need for special services, when comparing IVF singletons, IVF twins, or spontaneous twins; presumably, the risk for all three groups was higher than for spontaneous singletons. The results of these studies suggest that any increased risk of cerebral palsy associated with ART may be related to the increased risk of premature delivery and SGA.

In general, the available evidence on development in children born after infertility treatment is reassuring, although the majority of the studies have been relatively small, and several are limited by differential accrual and/or dropout. All of the studies identified in our search focused on children born after IVF and/or ICSI showed either no differences in scores on any standardized neurodevelopment or learning scale,^496,497^ or small differences that were explained by differences in other predictors such as paternal education level.^498,499^ A population-based case-control study in Denmark found a lower risk of autism after infertility treatment (OR 0.37; -95 percent CI 0.14–0.98);^500^ however, the diagnosis of autism in this case was based on hospital or clinic ratings.

2. Other systematic reviews. We did not identify any other systematic reviews relevant to this topic.

3. Conclusions. The available evidence suggests that there is not an increase in the risk of adverse neurodevelopmental outcomes in children born after infertility treatment that is not associated with the underlying condition of infertility or the well-established increased risk resulting from prematurity and SGA. The findings of the Scandinavian cerebral palsy studies, which show increased risks of cerebral palsy between IVF singletons compared with spontaneous singletons, but not IVF and spontaneous twins (or IVF singletons) are strikingly similar to the literature on prematurity and SGA among IVF singletons and twins described above. The available evidence on learning and other developmental outcomes is reassuring, but larger studies across a wider population are needed.

### VIII. Maternal Outcomes: Long-Term

A. Breast cancer. Long-term exposure to estrogen and/or progestins, manifested through such markers as early menarche, late menopause, nulliparity, and late onset of first pregnancy, has long been associated with an increased risk of breast cancer. Because these factors are also associated with infertility (especially anovulation^501^), and because many infertility treatments may lead to transient increases in estrogen and/or progesterone, infertility treatment could plausibly increase the risk of breast cancer.^502^ Because breast cancer is the most common cancer in women,^503^ even a relatively small increase in relative risk could translate into a large increase in the absolute risk.

1. Included studies. Included studies are summarized in Table 57. Consistently, use of clomiphene or gonadotropins was not significantly associated with an increased risk of breast cancer, especially when compared to other infertile controls and adjusted for other potential confounders such as age at followup and family history.

Table 57 Infertility treatments and breast cancer

Study | Exposure | | N | Measure of Association
RR/OR | Lower 95% CI | Upper 95% CI
Exposure to clomiphene and/or gonadotropins
Brinton et al., 2004^505^ | Reference | Population (standardized incidence ratio)
Brinton et al., 2004^505^ | | No exposure to clomiphene | | 1.28 | 1.1 | 1.5
Brinton et al., 2004^505^ | | Clomiphene | | 1.29 | 1.1 | 1.6
Brinton et al., 2004^505^ | | No exposure to gonadotropins | | 1.28 | 1.1 | 1.4
Brinton et al., 2004^505^ | | Gonadotropins | | 1.40 | 0.9 | 2.0
Study Type | Cohort ; n = 8431 | | Adjusted within-group risks (adjusted for age at followup, calendar year, site, and family history): clomiphene 1.02 (0.8, 1.3); gonadotropins 1.07 (0.7, 1.6). Risk estimates higher 20 years after exposure (clomiphene 1.39 (0.9, 2.1), gonadotropins 1.54 (0.8, 3.2).
Brinton et al., 2004^505^ | Reference | Population (standardized incidence ratio)
Brinton et al., 2004^505^ | | All subjects | | 1.29 | 1.1 | 1.4
Brinton et al., 2004^505^ | | Population (standardized mortality ratio) | | - | - | -
Brinton et al., 2004^505^ | | All subjects | | 1.58 | 1.1 | 2.2
Study Type | Cohort ; n = 8431 | | Same study as above; similar findings for mortality suggests no detection bias in patients with infertility
Burkman et al., 2003^507^ | Reference | Controls | 4682
Burkman et al., 2003^507^ | | Cases | 4575 | 0.9 | 0.8 | 1.2
Study type | Case-control | | Risk increased in women treated with hMG ≥ 6 months/cycles (ORs for all subgroups >2.0, 95% CIs do not include 1.0)
Terry et al., 2006^508^ | Reference | No infertility
Terry et al., 2006^508^ | | Ovulatory infertility, no induction | | 1.37 | 0.94 | 1.99
Terry et al., 2006^508^ | | Ovulatory infertility, induction | | 0.60 | 0.42 | 0.85
Terry et al., 2006^508^ | | Other infertility | | 0.67 | 0.35 | 1.25
Study type | Cohort; n = 116,741 | | Adjusted hazard ratios
Jensen et al., 2007 ^506^ | Reference | Infertility, no treatment
Jensen et al., 2007 ^506^ | | Gonadotropins | | 1.20 | 0.82 | 1.78
Jensen et al., 2007 ^506^ | | Clomiphene | | 1.08 | 0.85 | 1.39
Jensen et al., 2007 ^506^ | | hCG | | 0.94 | 0.73 | 1.21
Jensen et al., 2007 ^506^ | | GnRH | | 1.28 | 0.75 | 2.19
Jensen et al., 2007 ^506^ | | Progesterone | | 3.36 | 1.60 | 7.07
Study type | Cohort, n = 54,362
At least 1 cycle IVF
Dor et al., 2002^509^ | Reference | Population (standardized incidence ratio)
Dor et al., 2002^509^ | | IVF | | 0.69 | 0.46 | 1.66
Study Type | Cohort; n = 5026
Kristiansson et al., 2007^510^ | Reference | 1^st^ births
Kristiansson et al., 2007^510^ | | No IVF
Kristiansson et al., 2007^510^ | | IVF | | 0.74 | 0.40 | 1.26
Study Type | Cohort, n = 647,704 | | Women identified as having 1^st^ birth from 1988-2001
Venn et al., 2001^511^ | Reference | No IVF
Venn et al., 2001^511^ | | IVF | | 1.18 | 0.55 | 2.52
Study type | Cohort: n = 29,700; outcome: breast cancer death
Any infertility treatment
Gauthier et al., 2004^512^ | | Unexposed | 85948
Gauthier et al., 2004^512^ | | Any treatment | 6602 | 0.95 | 0.82 | 1.11
Gauthier et al., 2004^512^ | | Treated with drugs/IVF | | 0.94 | 0.78 | 1.12
Study Type | Cohort ; n = 92,550
Lerner-Geva et al., 2003^504^ | Reference | Population (SIR)
Lerner-Geva et al., 2003^504^ | | Any treatment | | 1.02 | 0.33 | 2.39
Study type | Cohort: n = 1082; any treatment for infertility 1984-1992 | | SIR decreased when cancers detected within 1^st^ year of infertility treatment excluded — detection bias
Lerner-Geva et al., 2007^513^ | Reference | Population (SIR)
Lerner-Geva et al., 2007^513^ | | Any treatment | | 1.14 | 0.95 | 1.40
Lerner-Geva et al., 2007^513^ | Reference | Untreated infertility
Lerner-Geva et al., 2007^513^ | | Treated infertility | | 1.11 | 0.79 | 1.56
Study type | Cohort: n = 5788; any treatment for infertility 1984-1992 | | SIR decreased when cancers detected within 1^st^ year of infertility treatment excluded — detection bias

Cancers diagnosed within a short time of the onset of treatment are unlikely to be caused by the treatment itself. The intensive schedule of medical contacts associated with medical treatment could lead to earlier detection; alternatively, treatment could increase the rate of growth enough to make a subclinical cancer present earlier (these explanations are not mutually exclusive). The included studies did not provide conclusive evidence for this effect. An Israeli study^504^ found that the standardized incidence ratio decreased when cases diagnosed within the first year after the beginning of treatment were excluded, consistent with both earlier detection and treatment-based acceleration of pre-existing tumors. On the other hand, a large U.S. cohort study^505^ found similar elevations in the standardized incidence ratio (SIR) and the standardized mortality ratio (SMR), suggesting similar stage distributions in infertile patients, which is inconsistent with earlier detection.

The same U.S. cohort study^505^ found some evidence of an increased risk 20 years after exposure, but these risks did not reach statistical significance (clomiphene OR 1.39; 95 percent CI 0.9–2.1; gonadotropins OR 1.54; 0.84–3.2). If this association is real, the number of cases should increase as the cohort of women who received treatment ages, since the incidence of breast cancer increases with age, allowing a more precise estimate of the risk.

The observed association of progesterone and breast cancer seen in a large Danish study^506^ should be interpreted with caution, since the actual number of reported exposures was much smaller than the number of women likely to have been exposed, given the ubiquity of progesterone for luteal support in ART.

2. Other systematic reviews. We did not identify any other systematic reviews.

3. Conclusions. In general, infertility treatments involving ovarian stimulation do not appear to be associated with an increased risk of breast cancer, although non-significantly elevated risks were seen 20 years after exposure in one study, suggesting that continued monitoring is warranted.

B. Ovarian cancer. Several case-control studies published in the 1990s reported a significant increase in the risk of ovarian cancer in women receiving ovulation stimulating drugs; the association was biologically plausible, since increased ovulation (early menarche, late menopause, nulliparity, no breast feeding, no use of oral contraceptives) has consistently been associated with an increased risk of breast cancer.^502^ Although ovarian cancer is not as common as breast cancer, the morality rate is much higher.^503^

1. Included studies. Included studies are summarized in Table 58. As with breast cancer, the association appears to be with infertility itself rather than with any particular treatment. For example, a large U.S. study found almost identical risks across all categories of clomiphene or gonadotropin use in a cohort of infertile patients.^514^ Of note, the risks were both higher (suggesting a stronger association) and had wider confidence intervals (reflecting the relative rarity of ovarian cancer compared to breast cancer) when compared to risks for breast cancer in the same study. As with breast cancer, there were non-significant increases with increasing duration since exposure; in addition, women who were nulliparous at the time of followup also had an increased risk (OR 1.75; 95 percent CI 0.5–5.7). In another publication from the same study,^515^ the risk was significantly elevated with primary infertility (OR 2.73; 1.8–4.0), but not secondary infertility (OR 1.44; 0.9–2.2). When stratified by infertility etiology, risks were significantly increased for endometriosis, tubal factor, and anovulation, but not for male, cervical, or uterine factor; because ovarian cancer arises from the surface of the ovary, it is biologically plausible that conditions which may result in abnormal stimulation of the ovary (such as PCOS) or inflammatory reactions of the ovarian surface (such as endometriosis or pelvic inflammation) would be associated with ovarian cancer, while infertility causes not associated with abnormalities of the ovary would not.

Table 58 Infertility treatments and ovarian cancer

Study | Exposure | | N | Measure of Association
RR/OR | Lower 95% CI | Upper 95% CI
Exposure to clomiphene and/or gonadotropins
Brinton et al., 2004^514^ | Reference | Population (SIR)
Brinton et al., 2004^514^ | | No exposure to clomiphene | | 2.09 | 1.4 | 3.0
Brinton et al., 2004^514^ | | Clomiphene | | 1.79 | 1.0 | 3.0
Brinton et al., 2004^514^ | | No exposure to gonadotropins | | 1.95 | 1.4 | 2.7
Brinton et al., 2004^514^ | | Gonadotropins | | 2.26 | 0.7 | 5.3
Study Type | Cohort ; n = 8429 | | Adjusted within-group risks non-significantly higher in women with > 12 cycles clomiphene (OR 1.54, 95% CI 0.5, 5.1) or > 9 cycles gonadotropins (OR 1.21, 95% CI 0.4, 3.9); or more than 15 years since exposure (clomiphene OR 1.48, 95% CI 0.7, 3.2; gonadotropin OR 2.46, 95% CI 0.7, 8.3). Risk also increased in women who were still nulliparous at followup (OR 1.75, 95% CI 0.5, 5.7). No other adjusted ORs above 1.2.
Brinton et al., 2004^515^ | Reference | Population (SIR)
Brinton et al., 2004^515^ | | Primary infertility | | 2.73 | 1.8 | 4.0
Brinton et al., 2004^515^ | | Secondary infertility | | 1.44 | 0.9 | 2.2
Study Type | Cohort ; n = 8429 | | Risks significantly increased for endometriosis, tubal factor, anovulation; not significant for male, cervical, uterine. Highest risk with endometriosis.
Parazzini et al., 2001^516^ | Reference | Controls | 2411
Parazzini et al., 2001^516^ | | Cases | 1031 | 1.35 | 0.71 | 2.57
Study type | Case-control
Rossing et al., 2004^517^ | Nulliparous | Controls | 311
Rossing et al., 2004^517^ | | Cases | 140 | 0.88 | 0.32 | 2.42
Rossing et al., 2004^517^ | Parous | Controls | 948
Rossing et al., 2004^517^ | | Cases | 613 | 0.85 | 0.45 | 1.59
Study type | Case-control | | Risk increased for nulliparous infertile women (1.59;1.01–2.50) but not for parous women with history of infertility (0.91; 0.69–1.19).
At least 1 cycle IVF
Dor et al., 2002^509^ | Reference | Population (SIR)
Dor et al., 2002^509^ | | IVF | | 0.57 | 0.01 | 3.2
Study Type | Cohort; n = 5026
Any infertility treatment
Lerner-Geva et al., 2003^504^ | Reference | Population (SIR)
Lerner-Geva et al., 2003^504^ | | Any treatment | | 5.0 | 1.02 | 14.6
Study type | Cohort: n = 1082; any treatment for infertility 1984-1992 | | SIR decreased when cancers detected within 1^st^ year of infertility treatment excluded — detection bias
Cusido et al., 2007^518^ | Reference | Controls
Cusido et al., 2007^518^ | | Any history of infertility | | 0.45 | 0.18 | 1.10
Study type | Case-control (controls benign ovarian surgery) | | Borderline tumors only
Tworoger et al., 2007^519^ | Reference | No infertility
Tworoger et al., 2007^519^ | | Female infertility | | 1.36 | 1.07 | 1.75
Tworoger et al., 2007^519^ | | Male infertility | | 1.23 | 0.68 | 2.25
Study type | Cohort, n=121,700 | | Adjusted for age, BMI, parity, history of tubal ligation, smoking history, age at menarche, age at menopause, duration of postmenopausal hormone use, and duration of oral contraceptive use

An Israeli cohort study^504^ found an increased SIR in women who received any treatment for infertility (SIR 5.0; 95 percent CI 1.02–14.6), but the SIR decreased when tumors detected within the first year of treatment were excluded, consistent with increased detection as part of the infertility evaluation, more rapid growth of prevalent tumors as the result of treatment, or both.

2. Other systematic reviews. We identified two systematic reviews. The first^520^ pooled data from eight case-control studies with 5207 cases and 7705 controls, adjusting for age, race, family history of ovarian cancer, duration of oral contraception use, tubal ligation, gravidity, education, and site. Time to pregnancy was significantly associated with risk (greater than 5 years compared to less than 1 year: OR 2.67; 95 percent CI 1.91–3.74). Fertility drug use was not associated with ovarian cancer among nulliparous, subfertile women (any use OR 1.60; 95 percent CI 0.90–2.87; greater than 12 months use OR 1.54; 0.45–5.27). An association with borderline tumors, but not invasive cancers, was found for fertility drug use in nulligravid women (OR 2.43; 95 percent CI 1.01–5.88). Certain causes of infertility were associated with ovarian cancer risk: endometriosis (OR 1.73; 1.10–2.71) and unexplained infertility (OR 1.19; 1.00–1.40).

The second review used published data from seven case-control studies and four cohort studies.^521^ Among case-control studies, cancer risk was increased when cases were compared to general population or hospital-based controls (OR 1.52; 95 percent CI 1.18–1.97), but not with infertile controls (OR 0.99; 0.67–1.45). An association was not observed in the cohort studies comparing treated and untreated subjects with infertility (adjusted hazard ratio 0.67; 95 percent CI 0.32–1.41).

3. Conclusions. Ovarian cancers are even more strongly associated with an infertility diagnosis than breast cancer; however, use of ovulation-stimulating drugs does not appear to increase the risk above baseline levels in this patient population. As with breast cancer, increasing risk with increased duration with treatment cannot be ruled out with confidence.

C. Other cancers. As with breast cancer, many of the risk factors associated with endometrial cancer are associated with infertility, especially anovulation.^501^ Data on associations with other cancers might provide insight into issues related to study design and interpretation.

1. Included studies. Identified studies are summarized in Table 59. We identified one case-control study examining the risk of endometrial cancer and use of fertility drugs,^522^ which found no association. One major limitation of this study is that exposure status was by self-report only, with no verification.

Table 59 Infertility treatments and other cancers

Study | Exposure | | N | Measure of Association
RR/OR | Lower 95% CI | Upper 95% CI
Endometrial cancer
Benshushan et al., 2001^522^ | | No fertility drugs | 128
Benshushan et al., 2001^522^ | | Any fertility drug | 255 | 1.43 | 0.53 | 3.81
Study Type | Case-control | | Exposure by self-report only
Any cancer
Kristiansson et al., 2007^510^ | Reference | No IVF
Kristiansson et al., 2007^510^ | | IVF | | 1.00 | 0.71 | 1.36
Study type | Cohort; n = 647,704 (1^st^ births) | | CIS of cervix significantly lower in IVF when date of conception used as start of followup — ?detected/treated prior to IVF referral
Lerner-Geva et al., 2003^504^ | Reference | Population (SIR)
Lerner-Geva et al., 2003^504^ | | Cervix | | 4.6 | 0.93 | 13.5
Lerner-Geva et al., 2003^504^ | | Other | | 2.05 | 0.98 | 3.78
Study type | Cohort: n = 1082; any treatment for infertility 1984-1992 | | SIR decreased when cancers detected within 1^st^ year of infertility treatment excluded—detection bias
Venn et al., 2001^511^ | Reference | No IVF
Venn et al., 2001^511^ | | IVF | | 0.72 | 0.46 | 1.13
Study type | Cohort: n = 29,700; outcome: cancer death

Two cohort studies examined the association with a variety of cancers. A Swedish study found no association, either globally (OR 1.00; 95 percent CI 0.71–1.36) or for individual cancers, although the risk of carcinoma in situ of the cervix was significantly lower in IVF patients when the date of conception, rather than the date of first treatment, was used as the start of followup.^510^ One explanation for this is that women undergoing infertility treatment are screened more intensively than similarly aged women, given that the screening interval in the Swedish program is 3 years in reproductive aged women;^523^ treatment of lesions detected during the infertility evaluation would lead to a decreased prevalence by conception, with subsequent decreased detection through screening. This provides supportive evidence that contact with the medical system during infertility evaluation and treatment may lead to increased detection of prevalent cancers. Similarly, an Israeli study^504^ found non-significantly increased SIRs for both cervix (SIR 4.6; 95 percent CI 0.93–13.5) and other non-reproductive cancers (SIR 2.05; 0.98–3.78), with a decrease in SIR when cancers detected within the first year after beginning treatment were excluded. This is consistent with an increased detection of prevalent cancers in this patient population, either through increased detection, acceleration of tumor growth, or both.

2. Other systematic reviews. We did not identify any other systematic reviews on this topic.

3. Conclusions. There is no available evidence suggesting an increased risk of other cancers with either infertility or infertility treatment. Available data on the incidence of preinvasive and invasive cervical cancer is consistent with increased detection as part of the infertility evaluation.

D. Other long-term outcomes. The inability to spontaneously conceive within a “normal” time frame, the nature of evaluation and treatment, and the risk of pregnancy or neonatal complications are all associated with significant emotional impact.^18,524^ This section discusses the available evidence on long-term psychological outcomes in parents.

1. Included studies. The majority of studies compared mean or median scores on validated quantitative scales. We summarize results for individual studies.

Post-partum. Fisher and colleagues^525^ found no significant difference in postpartum depression using the Edinburgh Postnatal Depression Scale between spontaneous, ovulation induction, or IVF mothers, but within the cohort of 745, there were only 12 ovulation induction pregnancies and 45 IVF pregnancies, limiting the study's power.

ART versus spontaneous conception: singletons. Three studies evaluated marital and parenting skills over time. McMahon and Gibson^526^ followed a cohort of 133 IVF and spontaneous singleton pregnancies through 12 months post-delivery, using both self-reported and observer-based scales. At 30 weeks, IVF mothers had lower self-esteem, greater external locus of control, and much higher anxiety about defects in baby and injury during birth, while fathers had lower self-esteem, higher trait anxiety, and lower marital satisfaction. At 4 months post-delivery, IVF infants had more fussing, but there were no significant differences in maternal behaviors (despite self-reported lower feelings of competence among IVF mothers). Finally, at 12 months, there were no differences in any self-reported items for mothers, but IVF fathers reported lower self-esteem and less caring from spouses. IVF mothers reported more difficult infants, but no differences in observed behaviors

In a Finnish cohort of 748 singleton pregnancies,^527^ overall parenting scores at 2 months post-delivery were higher for ART mothers, and increased significantly from 2 to 12 months, while parenting scores did not improve in the spontaneous conception group. Obstetric risk factors and problems and difficult child characteristics were negatively associated with parenting scores in the spontaneous group but not in the ART group. A second paper from this study found similar patterns for marital adjustment - overall marital functioning measured using standard scales was substantially better at 2 months post-partum for ART couples.^528^

Effect of multiple gestation. In an ART-only cohort, Ellison and colleagues^529^ compared singletons to twins to triplets among 249 ART conceptions. The prevalence of difficulty meeting material needs, lower quality of life, and social stigma were significantly increased in parents of multiples, with an evident dose-response: prevalences were higher in triplets than twins. Depression and lower marital satisfaction were also increased, but not significantly.

In a UK study,^530^ mothers of multiples were more likely to report significant parenting stress and depression, and less likely to be employed at 12 months than mothers of IVF or spontaneous singletons. Another study from the UK^531^ also found a significantly increased risk for post-partum depression (defined as a score greater than 12 on the Edinburgh Postnatal Depression Scale; RR 3.43; 95 percent CI 1.01–11.6).

Tully and colleagues^532^ found no differences in any scale of parental or child behavior at 5 years between spontaneous twins or twins from ovulation induction or IVF in a cohort of 242 twin pregnancies. In a Japanese cohort study of 990 multiples, Yokoyama and colleagues^533^ found depressive symptoms more common in infertility groups in univariate analysis; in multivariate analysis, the only significant predictors of depressive symptoms were at least one disabled child and no method for alleviating stress. The univariate association between infertility and depressive symptoms was likely due to a higher incidence of higher order multiples, because higher order multiples will deliver earlier on average (resulting in a greater risk of disability), and, for a given gestational age at delivery, larger numbers of children increase the likelihood that at least one of them will be disabled.

2. Other systematic reviews. We identified one systematic review on this topic.^534^ The review identified 27 relevant articles that included control groups and used validated instruments. At baseline, there were no substantial emotional differences in women undergoing IVF compared to controls; those that were present resolved with pregnancy. A subgroup of women had persistent emotional difficulties after unsuccessful IVF.

3. Conclusions. Based on the available literature, there are no differences in psychological outcomes, including parenting skills, when comparing singleton pregnancies resulting from ART to spontaneous conceptions. If anything, mothers of infants resulting from ART have better outcomes, although there is some evidence that fathers may do worse on some scales. Multiple gestations significantly increase stress and depressive symptoms, especially for mothers of infants with chronic disabilities; to the extent that women undergoing ART are more likely to experience multiples, especially preterm multiples, they are more likely to experience these symptoms. Clearly further research is needed. One caveat is that all of these studies were performed outside the United States - the extent to which differences in socioeconomic factors between couples undergoing ART in the United States and in other countries might affect these outcomes is unclear.