# Methods

This section describes the basic methodology used to develop the evidence report, including topic assessment and refinement, the analytic framework, literature search strategies and results, literature screening, quality assessment, data abstraction methods, and quality control procedures.

## Topic Assessment and Refinement

The National Institutes of Health (NIH) Office of Research on Women's Health (ORWH) and the Agency for Healthcare Research and Quality (AHRQ), sponsors of this report, and the other partners, the American College of Obstetrics and Gynecology (ACOG) and the Society for Assisted Reproductive Technology (SART), originally identified four key questions to be addressed by the report, which is intended to assess the evidence for the effectiveness and efficiency of assisted reproductive technology (ART). The Duke research team clarified and refined the overall research objectives and key questions by first consulting with AHRQ and the study partners, and then convening a national panel of technical experts to serve as advisors to the project. These experts were selected to represent relevant specialties. Members of the technical expert panel were:

- Kurt T. Barnhart, M.D., M.S.C.E.; Penn Fertility Care and Department of Obstetrics and Gynecology; University of Pennsylvania Health System; Philadelphia, PA
- Lisa Begg, Dr.P.H., R.N.; NIH Office of Research on Women's Health; Bethesda, MD
- David A. Grainger, M.D.; Center for Reproductive Medicine, Division of Reproductive Endocrinology, Department of Obstetrics and Gynecology; University of Kansas School of Medicine; Wichita, KS (representing SART)
- Joseph C. Isaacs; Resolve: The National Infertility Association; Bethesda, MD
- Julia V. Johnson, M.D.; Division of Reproductive Endocrinology and Infertility, Department of Obstetrics and Gynecology; University of Vermont and Fletcher Allen Health Care; Burlington, VT
- Richard E. Leach, M.D.; Division of Reproductive Endocrinology and Infertility, Department of Obstetrics and Gynecology; University of Illinois at Chicago; Chicago, IL
- Richard S. Legro, M.D.; Division of Reproductive Endocrinology, Department of Obstetrics and Gynecology; Milton S. Hershey Medical Center at Penn State; Hershey, PA
- Nancy O'Reilly, ACOG Committee for Practice Bulletins; Washington, DC
- Catherine Racowsky, Ph.D.; Center for Reproductive Medicine, Department of Obstetrics and Gynecology; Brigham and Women's Hospital; Boston, MA
- Robert W. Rebar, M.D.; American Society for Reproductive Medicine; Birmingham, AL
- Uma M. Reddy, M.D., M.P.H.; Pregnancy and Perinatology Branch, NIH National Institute of Child Health and Human Development; Bethesda, MD
- Laura E. Riley, M.D.; Vincent Obstetrics and Gynecology Services; Massachusetts General Hospital; Boston, MA

As a result of an initial conference call with the technical experts, AHRQ, ORWH, ACOG, and SART, the Duke research team finalized the key research questions to be included in the report and the approach that would be used to address them. The key questions are:

- Question 1: Among women of reproductive age (12–44), what factors identify couples with a low probability of spontaneously conceiving? Factors to be considered could include: age of mother, age of father, presence of endometriosis, prior conception history, body size, alcohol use, smoking, history of previous sexually transmitted infection, and results of infertility testing (hysterosalpingogram, diagnostic laparoscopy, blood tests for ovulatory function). In terms of our analytic framework, this question can be further refined into three separate broad questions:
  - Question 1a: What biological, environmental, or other factors increase the likelihood that a given couple will present with infertility or subfertility?
  - Question 1b: What biological, environmental, or other factors affect the likelihood of different outcomes of ovulation induction or ART?
  - Question 1c: What diagnostic tests are useful in helping predict the likelihood of different outcomes of ovulation induction or ART?
- Question 2: Among women of reproductive age, what are the benefits and risks of Clomid^®^ and Pergonal^®^ (or other injectable super-ovulatory drugs) and Glucophage^®^, and how do they vary in different patient populations?
  - Different patient populations include racial/ethnic groups and age by decade (or age groups comparable to those in the Centers for Disease Control (CDC)-SART national ART success rates reports^14^).
  - Risks include high rates of higher order multiples and ovarian hyperstimulation syndrome.
  - Benefits include reduced time to achieve pregnancy, correction of ovulatory dysfunction, possible decreased miscarriage rates, and decreased gestational diabetes risk with Glucophage^®^.
- Question 3: Among women of reproductive age, which laboratory, clinical, and other practice approaches result in the highest successful singleton pregnancy (or live-born) rates, and what practices lead to high multiple rates?
  - Laboratory practices include intracytoplasmic sperm injection (ICSI), different types of embryo culture, fresh versus frozen embryo transfer, and day 2 to 3 versus day 5 to 6 transfer.
  - Clinical practices include number of embryos transferred and selection criteria for eligible patients, as well as using the implantation rates from previous unsuccessful cycles to inform subsequent embryo transfer.
  - Other practices include insurance coverage strategies.
- Question 4: What are the adverse outcomes of ovulatory drug-induced pregnancies and of pregnancies achieved with in vitro fertilization (IVF)? Is there evidence to link these adverse outcomes with the treatments and not the underlying maternal health or gestational age problems?
  - For the mother, outcomes include preeclampsia, cesarean delivery, gestational diabetes, abruption, placenta previa, and breast and ovarian cancer.
  - For the infant, outcomes include birth defects, prematurity, low birth weight, and long-term outcomes as available.

After further discussion with the technical experts, AHRQ, ORWH, ACOG, and SART, it was agreed that we would not attempt a formal review of the literature pertaining to Question 1a. This was based on several factors. First, in our initial search of the recent literature, the majority of potentially relevant studies focused on environmental or occupational exposures. While identifying possible causal links between such exposures and subsequent infertility is clearly an important public health question, the state of the science does not allow immediately relevant clinical recommendations. For some exposures, there is substantial ongoing basic and clinical research (for example, in men and women exposed to cancer therapies as children or young adults), but these examples do not represent “typical” infertility practice, and warrant separate systematic review. Second, many of the best quality studies, particularly with respect to ascertainment of exposure, were performed outside the United States; for many exposures, this would limit their potential relevance to a U.S. population. Finally, in the United States, one of the most important factors that “increases the likelihood that a given couple will present with infertility or subfertility” is the availability of adequate insurance coverage or sufficient financial resources to cover diagnosis and treatment; wide variations in this availability could substantially affect risk estimates for the general population, especially in case-control studies

Given the large volume of the literature, the methodological complexities involved in interpreting the literature (in particular, the results of non-randomized studies of outcomes in subgroups and diagnostic tests), and the recent publication of several large relevant trials, the timeline for producing this draft report was extended. In order to expedite dissemination of the most immediately relevant results for clinical care, research, and policy, and after discussion with AHRQ, this initial draft is limited to Questions 2, 3, and 4 (those questions that focus on immediate and longer term outcomes); Questions 1b (subgroup analyses) and 1c (diagnostic and predictive testing) will be covered in a supplement to this draft.

For the sake of coherence, the sections below on the “Analytic Framework” and the “Literature Search and Review” include material relevant to all five of the final key questions (1b, 1c, 2, 3, and 4), while the sections on “Data Abstraction and Development of Evidence Tables” and “Quality Assessment Criteria” focus on Questions 2–4.

## Analytic Framework

We developed a simplified project-specific analytic framework to address the key questions within the context of a standardized evidence report (Figure 2). This framework incorporates etiologic causes, diagnostic evaluation, and treatment outcomes. Numbers refer to the research questions. The diagnostic classes of (a) ovulatory dysfunction, (b) unexplained subfertility/infertility, and (c) tubal factor and some male factor are not meant to be comprehensive or mutually exclusive, but represent broad diagnostic classes where ovulation induction and/or ART are generally considered appropriate therapy.

Figure 2. Analytic framework for evidence report. Numbers refer to key questions

Briefly, Question 1 addresses etiology and patient-specific characteristics that affect the likelihood of different treatment outcomes, Question 2 addresses short-term treatment outcomes after therapy with ovulation-inducing therapies, Question 3 addresses short-term treatment outcomes with ART, and Question 4 addresses longer term outcomes for both mothers and infants after both ovulation induction and ART.

## Literature Search and Review

### I. Sources

The primary source of literature was MEDLINE^®^ (1966–January Week 4 2008). Searches of this database were supplemented by a search of the Cochrane Database of Systematic Reviews, and by a review of the reference lists of included articles and relevant review articles and meta-analyses.

### II. Search Strategies

The basic MEDLINE^®^ search strategy used the National Library of Medicine's Medical Subject Headings (MeSH) key word nomenclature. Searches were limited to articles published in English. The exact search string used is given in Appendix A.^*^ Relevant reviews in the Cochrane Database of Systematic Reviews were identified by hand searching the list of reviews published by the Menstrual Disorders and Subfertility Group, which covers all topics relevant to this report. All search strategies combined yielded a total of 5294 citations, whose records are maintained in a ProCite (Thompson ISI ResearchSoft, Berkeley, CA) database.

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/reprotech/reprotech.pdf

### III. Screening of Abstracts

Paired clinicians from the Duke research team independently reviewed abstracts and classified each as included or excluded according to project-specific criteria, which they also developed. An abstract was included for full-text review if at least one of the paired reviewers recommended that it be included.

The inclusion criteria applied at the abstract screening stage were:

- N ≥ 50 if not a randomized controlled trial (RCT; smaller RCTs were acceptable); and
- Female age ≤ 45; and
- Study relevant to at least one of the key questions, as follows:
  - Compares outcomes of ovulation induction or ART based on presence/absence or differing levels of biological, environmental, or other factors (Question 1b); and/or
  - Reports sensitivity/specificity of diagnostic tests for predicting the likelihood of different outcomes of ovulation induction or ART; or study reports “associations” or “correlations” between test results and outcomes (Question 1c); and/or
  - Reports benefits and risks of treatment with Clomid^®^, Pergonal^®^, other injectable super-ovulatory drugs, or Glucophage^®^ in various populations (Question 2); and/or
  - Reports pregnancy and/or live birth rates of ART (Question 3); and/or
  - Reports adverse outcomes (including quality-of-life measures) of ovulatory drug-induced pregnancies and of pregnancies achieved with IVF based on either (i) history of infertility or (ii) treatment (Question 4).

When these screening criteria were applied, a total of 2712 citations were included for further review at the full-text stage.

### IV. Screening of Full Texts

At the full-text screening stage, paired researchers independently reviewed the articles that had passed the abstract screening and indicated a decision to include or exclude them for data abstraction for one or more of the key questions. When the two reviewers arrived at different decisions about inclusion/exclusion or about question assignment for a given article, they were asked to reconcile their differences. The question-specific screening criteria applied at the full-text stage are described in Table 1.

Table 1 Full-text screening criteria by question

Question 1b (biological, environmental, and other factors affecting the likelihood of different outcomes of ovulation induction or ART): Include when:; - Article published from 2000-present; and; - N ≥ 100; and; - Female age ≤ 45; and; - Study compares outcomes of ovulation induction/ART based on presence/absence or differing levels of factor; and; - Outcomes include (a) pregnancy and/or live birth; (b) multiple pregnancy; and/or (c) adverse outcomes; and; - Outcomes are reported or calculable on a per-patient or per-couple basis; and; - Able to construct 2-by-2 table for outcomes based on data provided in the paper.; - Include donor egg if (and only if) an explicit comparison to non-donor egg pregnancies is made.; Notes:; - Factors to be considered include:; - Age of mother; - Age of father; - Presence of endometriosis; - Prior conception history; - Body size; - Alcohol use; - Smoking; - History of previous sexually transmitted infection
Question 1c (diagnostic tests for predicting the likelihood of different outcomes of ovulation induction or ART): Include when:; - Article published from 2000-present; and; - N ≥ 100; and; - Female age ≤ 45; and; - Study reports sensitivity/specificity of diagnostic test in predicting outcome of ovulation induction/ART; or study reports “associations” or “correlations” between test results and outcomes; and; - Outcomes include pregnancy and/or live birth; and; - Outcomes are reported/calculable on a per-patient or per-couple basis, or outcomes are reported/calculable on a per-cycle basis if test is repeated each cycle (e.g., embryo quality score prior to implantation would be repeated each cycle, and analysis on a per-cycle basis would be appropriate; maternal blood tests performed only prior to treatment should have results presented/calculable per-patient/couple, rather than per-cycle); and; - Able to construct 2-by-2 table for outcomes based on data provided in the paper.; Exclude when study uses donor egg or sperm. Notes:; - Diagnostic tests include:; - Hysterosalpingogram; - Diagnostic laparoscopy; - Blood tests for ovulatory function
Question 2 (benefits and risks of Clomid Glucophage^®^, Pergonal^®^, other injectable super-ovulatory drugs, and Glucophage^®^ in various populations): Include when:; - Article published from 2000-present; and; - Study design = RCT; and; - Female age ≤ 45; and; - Study reports outcomes of treatment with drugs for ovulation induction, including:; - Clomiphene; - Tamoxifen; - Human menopausal gonadotropins; - GnRH agonists; and; - Outcomes include pregnancy and/or live birth, and data are reported or calculable on a per-patient or per-couple basis.; Exclude when study uses donor egg or sperm. Notes:; - Different patient populations include:; - Racial/ethnic groups; - Age by decade (or age groups comparable to CDC-SART national ART success rates reports^14^); - Risks include high rates of higher order multiples and ovarian hyperstimulation syndrome; - Benefits include:; - Reduced time to achieve pregnancy; - Correction of ovulatory dysfunction; - Possible decreased miscarriage rates; - Decreased gestational diabetes risk with Glucophage^®^
Question 3 (laboratory, clinical, and other practices resulting in the highest successful singleton pregnancy (or live-born) rates, and practices leading to high multiple rates): Include when:; - Article published from 2000-present; and; - Study design = RCT; and; - Female age ≤ 45; and; - Study reports pregnancy and/or live birth rates of ART, and data are reported or calculable on a per-patient basis or per-couple basis.; Exclude when study uses donor egg or sperm. Notes:; - Laboratory practices include:; - Intracytoplasmic sperm injection (ICSI); - Different types of embryo culture; - Fresh versus frozen embryo transfer; - Day 2–3 versus day 5–6 transfer; - Clinical practices include:; - Number of embryos transferred; - Selection criteria for eligible patients; - Using the implantation rates from previous unsuccessful cycles to inform subsequent embryo transfer; - Other practices include insurance coverage strategies
Question 4 (adverse outcomes of ovulatory drug-induced pregnancies and of pregnancies achieved with IVF): Include when:; - Article published from 2000-present; and; - If not an RCT, N ≥ 100 (this refers to the total number of patients, not the number of cases, which may be < 100); and; - Female age ≤ 45; and; - Study reports pregnancy-related outcomes based on either (a) history of infertility or (b) treatment (note that such outcomes can include quality-of-life measures); and; - Study reports short- or long-term neonatal and maternal outcomes (listed below) on a per-patient, per-pregnancy, or per-birth basis.; - Include donor egg if (and only if) explicit comparison made to non-donor egg pregnancies.; Exclude non-U.S. studies that do not report base rates of incidence for comparison group. Notes:; - For the mother, outcomes include:; - Preeclampsia; - Cesarean delivery; - Gestational diabetes; - Abruption; - Placenta previa; - Breast, ovarian, and other cancers; - Quality-of-life measures; - For the infant, outcomes include:; - Birth defects; - Prematurity; - Low birth weight; - Long-term outcomes as available; - Quality-of-life measures

Summaries of the results of the abstract screening and full-text review are provided in Tables 2 and 3. A list of excluded articles, with reasons for exclusion, is provided in Appendix B.

Table 2 Results of abstract and full-text screening

Articles identified | 5294
Abstracts screened | 5294
Included | 2712
Excluded | 2582
Full-text articles screened | 2712
Included for at least one question | 818
Excluded for at least one question | 1942
Included for at least one question and excluded for at least one other question | 48

Table 3 Included full-text articles by question

Question | Number of articles
Question 1b: Biological, environmental, and other factors affecting outcomes of ovulation induction/ART | 131
Question 1c: Diagnostic tests | 229
Question 2: Ovulation induction with assisted conception | 63
Question 3: Assisted conception: IVF and ICSI | 237
Question 4: Longer-term outcomes | 178
Total number of articles included for data abstraction^†^ | 818

† Some articles were included for more than one question.

## Data Abstraction and Development of Evidence Tables

The Duke research team developed data abstraction forms/evidence table templates for abstracting data for each of the key questions; the forms used for Questions 2–4 are provided in Appendix C. Based on clinical expertise, a pair of researchers was assigned to each key question to abstract data from the eligible articles. One of the pair abstracted the data, and the other over-read the article and the accompanying abstraction to check for accuracy and completeness. At this stage of the review, included articles were also assigned to specific topics within each key question. The completed evidence tables for Questions 2–4 are provided in Appendix D.

The evidence tables include estimates of appropriate summary measures. For Questions 2 and 3, which were limited to RCTs, we calculated the relative risk of clinical pregnancy, live birth, or both, associated with treatment, along with 95 percent confidence intervals, using a Microsoft Excel^®^ spreadsheet incorporating the appropriate formulas. When possible, no treatment or placebo was used as the reference; if an active control was used, we attempted to use those therapies that reflected “standard of care,” as defined by the study authors or based on input from the clinicians on the Duke team. Whenever possible, the denominator for these ratios was the number of women or couples randomized.

For Question 4, we similarly estimated the relative risk (for RCTs and cohort studies) or the odds ratio (for case-control studies), along with 95 percent confidence intervals.

Relevant meta-analyses identified by our search (including all relevant Cochrane reviews) were not abstracted, but results are summarized in the text.

## Quality Assessment Criteria

At the data abstraction stage, abstractors were asked to evaluate each included article for factors affecting internal and external validity. The quality assessment criteria used for this purpose were developed by the Tufts-New England Medical Center Evidence-based Practice Center (EPC) for an evidence report on “Effects of Omega-3 Fatty Acids on Cardiovascular Disease.”^38^ Abstractors were instructed to assign a “+” or “-” to each item and provide a brief rationale for their decisions.

The quality criteria assessed for Questions 1b and 1c will be described in a supplement to this report. For Questions 2–4, the criteria were:

For Questions 2 and 3:

- Randomization method
- Blinding
- Dropout rate < 20%
- Adequacy of randomization concealment

For Question 4:

For RCTs:

- Randomization method
- Blinding
- Dropout rate < 20%
- Adequacy of randomization concealment

For cohort studies:

- Unbiased selection of the cohort (prospective recruitment of subjects)
- Large sample size
- Adequate description of the cohort
- Use of validated method for ascertaining exposure
- Use of validated method for ascertaining clinical outcomes
- Adequate followup period
- Completeness of followup
- Analysis (multivariate adjustments) and reporting of results

For case-control study:

- Valid ascertainment of cases
- Unbiased selection of cases
- Appropriateness of the control population
- Comparability of cases and controls with respect to potential confounders
- Appropriateness of statistical analyses

After some deliberation, we decided not to assign individual studies a summary quality score (see, e.g., the “A, B, C” scale used in previous evidence reports by the Tufts-New England Medical Center EPC, including in the report cited above^38^). First, there is no evidence that the use of any particular quality scoring system has a substantial impact on the results of systematic reviews.^39^ Second, our experience has been that it is more helpful to identify consistent and specific quality issues that affect the majority of the literature (concerning, e.g., sample size, analytic methods, or ascertainment bias) in order to guide future research, rather than relying on a global quality score.

## Peer Review Process

We employed internal and external quality-monitoring checks through every phase of the project to reduce bias, enhance consistency, and verify accuracy. Examples of internal monitoring procedures include: three progressively stricter screening opportunities for each article (abstract screening, full-text screening, and data abstraction); involvement of three individuals (two clinicians and a copy-editor) in each data abstraction; and agreement of at least two clinicians on all included studies.

Our principle external quality-monitoring device is the peer-review process. Nominations for peer reviewers were solicited from several sources, including the technical expert panel (who also served as reviewers) and interested Federal agencies. The list of nominees was forwarded to AHRQ for vetting and approval. A list of reviewers submitting comments on this draft is included in Appendix E.