# Appendix E: Peer Reviewers

The Duke Evidence-based Practice Center is grateful to the following peer reviewers who read and commented on a draft version of this report:

Kurt T. Barnhart, M.D., M.S.C.E.; Penn Fertility Care and Department of Obstetrics and Gynecology; University of Pennsylvania Health System; Philadelphia, PA

Barbara Collura, M.A.; Resolve: The National Infertility Association; Bethesda, MD

Miriam Kuppermann, Ph.D., M.P.H.; Department of Obstetrics, Gynecology and Reproductive Sciences; University of California at San Francisco; San Francisco, CA

Richard S. Legro, M.D.; Division of Reproductive Endocrinology, Department of Obstetrics and Gynecology; Milton S. Hershey Medical Center at Penn State; Hershey, PA

Julius Patterson; Office of Communications and Knowledge Transfer, Agency for Healthcare Research and Quality; Rockville, MD

Catherine Racowsky, Ph.D.; Center for Reproductive Medicine, Department of Obstetrics and Gynecology; Brigham and Women's Hospital; Boston, MA

Robert W. Rebar, M.D.; American Society for Reproductive Medicine; Birmingham, AL

Uma M. Reddy, M.D., M.P.H.; Pregnancy and Perinatology Branch, NIH National Institute of Child Health and Human Development; Bethesda, MD