# Appendix D: Evidence Tables

Evidence Table 1. Question 2 - Ovulation Induction without Assisted Conception

Study | Study Design | Patients | Clinical Presentation | Results | | | | Comments/Quality Scoring
Al-Fadhli, Sylvestre, Buckett, et al., 2006 #50070 | Geographical location: Montreal, Canada Study dates: Mar 2004–Jan 2005 Size of population (no. of patients): 72 Number of cycles analyzed: 72 Number of cycles per patient: 1 Study type: RCT Interventions: Population: Patients undergoing superovulation and IUI Compare 2.5 vs. 5 mg daily dose of letrozole administered from day 3–7 When at least 1 follicle > 18 mm, 10,000 U hCG SC administered and IUI performed 24–48 hours later | Age: Mean (SD): 2.5mg: 31.8 ± 0.3 5mg: 31.8 ± 0.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 72 (100%) Inclusion criteria:; - Infertility > 1 year; - Age < 40 years; - Menstrual cycle 25–35 days; - Patent tubes on HSG; - Normal semen analysis; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + urine hCG or serum β-hCG > 10 mIU/ml with intrauterine gestational sac Live birth: NR Multiples: Yes Complications: OHSS | 1) Pregnancy: | | | | Comments:; - No information about blinding; - 2.5 mg and 5 mg dose may look different; - No information about allocation concealment; Quality assessment: Randomization method: + Blinding: - (not discussed) Dropout rate < 20%: + Adequacy of randomization concealment: - (not discussed)
Al-Fadhli, Sylvestre, Buckett, et al., 2006 #50070 | | | Definition(s) of outcome(s): Pregnancy: + urine hCG or serum β-hCG > 10 mIU/ml with intrauterine gestational sac Live birth: NR Multiples: Yes Complications: OHSS | | Preg + | Preg -
Al-Fadhli, Sylvestre, Buckett, et al., 2006 #50070 | | | Definition(s) of outcome(s): Pregnancy: + urine hCG or serum β-hCG > 10 mIU/ml with intrauterine gestational sac Live birth: NR Multiples: Yes Complications: OHSS | 5mg | 10 | 28 | 38
Al-Fadhli, Sylvestre, Buckett, et al., 2006 #50070 | | | Definition(s) of outcome(s): Pregnancy: + urine hCG or serum β-hCG > 10 mIU/ml with intrauterine gestational sac Live birth: NR Multiples: Yes Complications: OHSS | 2.5mg | 2 | 32 | 34
Al-Fadhli, Sylvestre, Buckett, et al., 2006 #50070 | | | Definition(s) of outcome(s): Pregnancy: + urine hCG or serum β-hCG > 10 mIU/ml with intrauterine gestational sac Live birth: NR Multiples: Yes Complications: OHSS | | 12 | 60 | 72
Al-Fadhli, Sylvestre, Buckett, et al., 2006 #50070 | | | Definition(s) of outcome(s): Pregnancy: + urine hCG or serum β-hCG > 10 mIU/ml with intrauterine gestational sac Live birth: NR Multiples: Yes Complications: OHSS | | | Lower 95% CI | Upper 95 % CI
Al-Fadhli, Sylvestre, Buckett, et al., 2006 #50070 | | | Definition(s) of outcome(s): Pregnancy: + urine hCG or serum β-hCG > 10 mIU/ml with intrauterine gestational sac Live birth: NR Multiples: Yes Complications: OHSS | Rel risk | 4.47 | 1.05 | 19.00
Al-Fadhli, Sylvestre, Buckett, et al., 2006 #50070 | | | Definition(s) of outcome(s): Pregnancy: + urine hCG or serum β-hCG > 10 mIU/ml with intrauterine gestational sac Live birth: NR Multiples: Yes Complications: OHSS | 2) No multiple pregnancies
3) No ovarian hyperstimulation
Al-Fozan, Al-Khadouri, Tan, et al. 2004 #11710 | Geographical location: Montreal, Quebec, Canada Study dates: Jul 2002–Sep 2003 Size of population: 154 Number of cycles analyzed: 238 Number of cycles per patient: 1.8 Study type: RCT Interventions: Compared the use of letrozole vs. CC in pts undergoing ovulation induction | Age: Mean (SD): Letrozole: 30.7 (0.5) CC: 31.5 (0.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 100% Inclusion criteria:; - Infertility at least 1 yr; - Patent tubes by HSG; - Normal semen analysis; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy rate: | | | | Comments: Did not provide definition of pregnancy Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Al-Fozan, Al-Khadouri, Tan, et al. 2004 #11710 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: Did not provide definition of pregnancy Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Al-Fozan, Al-Khadouri, Tan, et al. 2004 #11710 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Letroz | 13 | 61 | 74 | Comments: Did not provide definition of pregnancy Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Al-Fozan, Al-Khadouri, Tan, et al. 2004 #11710 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | CC | 11 | 69 | 80 | Comments: Did not provide definition of pregnancy Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Al-Fozan, Al-Khadouri, Tan, et al. 2004 #11710 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 24 | 130 | 154 | Comments: Did not provide definition of pregnancy Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Al-Fozan, Al-Khadouri, Tan, et al. 2004 #11710 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | value | | | Comments: Did not provide definition of pregnancy Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Al-Fozan, Al-Khadouri, Tan, et al. 2004 #11710 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.28 | 0.61 | 2.67 | Comments: Did not provide definition of pregnancy Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Al-Fozan, Al-Khadouri, Tan, et al. 2004 #11710 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 2) Pregnancy outcome: | | | | Comments: Did not provide definition of pregnancy Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Al-Fozan, Al-Khadouri, Tan, et al. 2004 #11710 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Letrozole: 11.5% (13 pts); - 11 ongoing pregnancy; - 2 ectopic pregnancy | | | | Comments: Did not provide definition of pregnancy Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Al-Fozan, Al-Khadouri, Tan, et al. 2004 #11710 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Clomid: 8.9% (11 pts); - 7 ongoing pregnancy (one set of twins); - 4 ectopic pregnancy | | | | Comments: Did not provide definition of pregnancy Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
No statistically significant difference between 2 groups.
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | Geographical location: Alexandria, Egypt Study dates: NR Size of population: 97 Number of cycles analyzed: 316 Number of cycles per patient: 3.26 Study type: RCT Interventions: Compare ovulation induction protocol using Ketoconazole (CYP17a antagonist) pretreatment for 85 days prior to CC treatment with CC alone. Population: Insulin resistant PCOS pts | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: NR Endometriosis: NR Male factor: 0 Tubal factor: NR PCOS: 0 Inclusion criteria:; - PCOS and insulin resistance; - Normal semen analysis; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | 1) Pregnancy rate (intention-to-treat): | | | | Comments:; - Baseline patient characteristics not described; - Unblinded, no placebo; - No intention-to-treat analysis in paper; - Did continue treatment for multiple cycles—greater number of cycles in ketoconazole group; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | | Preg + | Preg -
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | Keto + CC | 17 | 32 | 49
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | CC only | 8 | 40 | 48
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | | 25 | 72 | 97
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 2.08 | 0.99 | 4.36
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | 2) Live births:
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | | LB + | LB -
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | Keto + CC | 16 | 33 | 49
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | CC only | 7 | 41 | 48
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | | 23 | 74 | 97
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 2.24 | 1.01 | 4.95
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | 3) Multiple pregnancy:
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | | Multi + | Multi -
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | Keto + CC | 8 | 9 | 17
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | CC only | 6 | 2 | 8
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | | 14 | 11 | 25
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 0.63 | 0.33 | 1.19
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | 4) Cycles per subject:
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | Ketoconazole + CC: 3.7
Ali Hassan, El-Gezeiry, Nafaa, et al., 2001 #3190 | | | Definition(s) of outcome(s): Pregnancy: + hCG Live birth: Yes Multiples: Yes Complications: NR | CC only: 2.8
Higher drop-out rate in clomiphene only
Allegra, Marino, Coffaro, et al., 2007 #50110 | Geographical location: Palermo, Italy Study dates: May 2002–Dec 2004 Size of population (no. of patients): 104 Number of cycles analyzed: 302 Number of cycles per patient: 302/104 = 2.9 cycles per patient Study type: RCT Interventions: Population: Women undergoing controlled ovarian stimulation (COS)/IUI treatment Compare the use of recombinant FSH (rFSH) with GnRH antagonist Cetrorelix vs. rFSH alone rFSH + Cetrorelix: rFSH 75–150 IU per day depending on age (≤ 30 vs. > 30 years) for 5 days. Cetrorelix 0.25 mg per day when follicle ≥ 14 mm only if LH was < 10 mIU/ml, progesterone l< 2ng/ml and E2 > 200 pg/ml. When leading follicle 18 mm, 10,000 IU hCG given and Cetrorelix discontinued. rFSH: same regimen as above 2 inseminations performed 20 and 34 hrs after hCG. All women given natural micronized progesterone 400 mg per day vaginally in 2 divided doses started 2 days after 2^nd^ IUI. | Age: Mean (SD): rFSH + Cetrolex: 33.0 ± 4.0 rFSH only: 32.5 ± 3.6 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 63 (60%) Endometriosis: 4 (4%) Mild male factor: 37 (36%) Inclusion criteria:; - Unexplained infertility or mild male factor infertility (abnormal semen variables but normal morphology 5% and total number of motile spermatozoa after Pellet Swim-up ≥ 5×10^6^/ml) or minimal to mild endometriosis (stage I–II); - Age > 18 but ≤ 38; - BMI between 18–30kg/m^2^; - Normal menstrual cycles 24–35 days; - Normal basal serum FSH, TSH and prolactin; - Normal uterine cavity and bilateral tubal patency by HSG and/or hydolaparoscopy with chromosalpingography and hysteroscopy; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: β-hCG 2 wk after IUI and TVUS 6–7 weeks gestation to detect fetal cardiac activity Live birth: NR Multiples: Higher order multiples defined by 3 or more gestational sacs at US Complications: Ovarian hyperstimulation (not defined) | 1) Pregnancy (intention-to-treat): | | | | Comments:; - Regimens are different so blinding affected; - No placebo for Cetrorelix; Quality assessment: Randomization method: + Blinding: - (regimens are different and no placebo for Cetrorelix) Dropout rate < 20%: + Adequacy of randomization concealment: +
Allegra, Marino, Coffaro, et al., 2007 #50110 | | | | | Preg + | Preg -
Allegra, Marino, Coffaro, et al., 2007 #50110 | | | | rFSH + Cetrorelix | 28 | 24 | 52
Allegra, Marino, Coffaro, et al., 2007 #50110 | | | | rFSH only | 16 | 36 | 52
Allegra, Marino, Coffaro, et al., 2007 #50110 | | | | | 44 | 60 | 104
Allegra, Marino, Coffaro, et al., 2007 #50110 | | | | | | Lower 95% CI | Upper 95 % CI
Allegra, Marino, Coffaro, et al., 2007 #50110 | | | | Rel risk | 1.75 | 1.08 | 2.83
Allegra, Marino, Coffaro, et al., 2007 #50110 | | | | 2) Twin gestations (intention-to-treat):
Allegra, Marino, Coffaro, et al., 2007 #50110 | | | | | Preg + | Preg -
Allegra, Marino, Coffaro, et al., 2007 #50110 | | | | rFSH + Cetrorelix | 4 | 48 | 52
Allegra, Marino, Coffaro, et al., 2007 #50110 | | | | rFSH only | 1 | 51 | 52
Allegra, Marino, Coffaro, et al., 2007 #50110 | | | | | 5 | 99 | 104
Allegra, Marino, Coffaro, et al., 2007 #50110 | | | | | | Lower 95% CI | Upper 95 % CI
Allegra, Marino, Coffaro, et al., 2007 #50110 | | | | Rel risk | 4.00 | 0.46 | 34.59
Allegra, Marino, Coffaro, et al., 2007 #50110 | | | | 3) No higher order multiples
4) No ovarian hyperstimulation
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | Geographical location: Benha, Egypt Study dates: Oct 2003–Apr 2005 Size of population (no. of patients): 804 Number of cycles analyzed: 804 Number of cycles per patient: 1 Study type: RCT Interventions: Population: women with unexplained infertility Compare CC with N-acetyl-cysteine (NAC) vs. CC alone CC + NAC = CC 50 mg bid and NAC 1200 mg/d po for 5 days starting cycle day 2 CC + sugar placebo = CC same dose as above and sugar with the same volume as NAC | Age: Mean (SD): CC+NAC: 27.9 ± 4.2 CC+placebo: 28.1 ± 3.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 804 (100%) Inclusion criteria:; - 1 year of continuous marriage without conception; - Patent fallopian tubes by HSG; - Normal ovulating cycles by midluteal serum progesterone levels; - Normal laparoscopic findings; - Normal semen analysis; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | 1) Pregnancy: | | | | Comments:; - Blinding might be affected if patients detect a different taste between NAC and sugar; - No information about randomization method but sealed envelopes were used; Quality assessment: Randomization method: - Blinding: + (radiologist and lab personnel were blinded, patients might not be blinded if taste of sugar and NAC was different) Dropout rate < 20%: + Adequacy of randomization concealment: +
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | | | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | | Preg + | Preg -
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | | | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | CC+NAC | 90 | 314 | 404
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | | | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | CC+placebo | 108 | 292 | 400
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | | | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | | 198 | 606 | 804
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | | | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | | | Lower 95% CI | Upper 95 % CI
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | | | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | Rel risk | 0.83 | 0.65 | 1.05
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | | | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | 2) Multiple gestation:
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | | | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | | Multi + | Multi -
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | | | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | CC+NAC | 8 | 396 | 404
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | | | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | CC+placebo | 12 | 388 | 400
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | | | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | | 20 | 784 | 804
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | | | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | | | Lower 95% CI | Upper 95 % CI
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | | | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | Rel risk | 0.66 | 0.27 | 1.60
Badawy, Baker El Nashar, and El Totongy, 2006 #50330 | | | Definition(s) of outcome(s): Pregnancy: + hCG in the absence of menstruation 2 weeks after hCG administration Live birth: NR Multiples: Yes Complications: Miscarriage, OHSS (no definition provided) | 3) No difference in miscarriage rates (CC + NAC 6.7% vs. CC + placebo 7.4%)
4) No cases of OHSS
Balasch, Fabregues, Creus, et al., 2001 #5560 | Geographical location: Barcelona, Spain Study dates: NR Size of population (no. of patients): 29 Number of cycles analyzed: 26 subjects each 2 cycles 3 subjects just 1 cycle Number of cycles per patient: As above Study type: RCT Interventions: Population: CC-resistant chronic anovulatory infertility treated with 2 different recombinant human FSH regimens Step up regimen: start dose 75 IU and increased by 37.5 IU after 14 days if no ovarian response on US (i.e. no follicle ≥ 10 mm). Additional dose increases after 7 day period if necessary. Increase until ovarian response seen on US then same dose continued until follicle > 17 mm.; - hCG 10000 IU to induce ovulation. Hcg held if ≥ 4 follices were > 14 mm.; Step down regimen: start dose 300 IU (cycle day 3) f/b 3 days free of treatment (cycle days 4–6). rhFSH restarted on day 7 with 75 IU until day 9. Then protocol the same as the step up method. Each woman received both treatment approaches with an interval of ≥ 1 month between treatments. Data for 1^st^ cycle before cross-over are presented | Age: Mean (SD): 31.1±0.6 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 26 (100%) Inclusion criteria:; - Failed to ovulate with CC or not conceived after at least ovulatory cycles on CC at doses ≤ 200 mg/d for 5 days; Exclusion criteria:; - Abnormal male partner semen parameters; - Abnormal HSG or laparoscopy; - History of pelvic surgery or PID | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS, definition NR | 1) Pregnancy (intention-to-treat): | | | | Comments:; - Randomization method and allocation concealment were not discussed; - No blinding because entirely different regimens for step up and step down; Quality assessment: Randomization method: - (no discussion regarding method) Blinding: - (no blinding because regimens were different) Dropout rate < 20%: + Adequacy of randomization concealment: - (no discussion regarding concealment)
Balasch, Fabregues, Creus, et al., 2001 #5560 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS, definition NR | Data for 1^st^ cycle before crossover
Balasch, Fabregues, Creus, et al., 2001 #5560 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS, definition NR | | Preg + | Preg -
Balasch, Fabregues, Creus, et al., 2001 #5560 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS, definition NR | Step up | 2 | 13 | 15
Balasch, Fabregues, Creus, et al., 2001 #5560 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS, definition NR | Step down | 1 | 13 | 14
Balasch, Fabregues, Creus, et al., 2001 #5560 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS, definition NR | | 3 | 26 | 29
Balasch, Fabregues, Creus, et al., 2001 #5560 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS, definition NR | | | Lower 95% CI | Upper 95 % CI
Balasch, Fabregues, Creus, et al., 2001 #5560 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS, definition NR | Rel risk | 1.87 | 0.19 | 18.38
2) No cases of ovarian hyperstimulation
Bayar, Tanriverdi, Barut, et al., 2006 #60050 | Geographical location: Zonguldak, Turkey Study dates: Jan 2002–Jan 2003 Size of population (no. of patients): 50 (4 in letrozole lost to follow-up) Number of cycles analyzed: 119 Number of cycles per patient: 2.6 Study type: RCT Interventions: Letrozole 200 mg/day days 3–7 vs clomiphene 100 mg/day days 3–7; IUI in subjects with borderline male infertility | Age: Median (range): Letrozole: 31 (23–39) Clomiphene: 31 (24–39) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR, but limited to unexplained infertility, early stage endometriosis, and mild male infertility Inclusion criteria:; - Infertility lasting > 1 year; - Documentation of ovulation with midluteal serum P levels > 5 ng/mL (conversion factor 3.18 nmol/L), normal hormonal profile (TSH, PRL, T, and DHEAS), and day 3 FSH ≤ 12 IU/L; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 1) Clinical pregnancy per randomized patient: | | | | Comments: Alternate odd-even numbers; included only because included in Cochrane review Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bayar, Tanriverdi, Barut, et al., 2006 #60050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total
Bayar, Tanriverdi, Barut, et al., 2006 #60050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Letrozole | 5 | 20 | 25
Bayar, Tanriverdi, Barut, et al., 2006 #60050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | CC | 8 | 17 | 25
Bayar, Tanriverdi, Barut, et al., 2006 #60050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Total | 13 | 37 | 50
Bayar, Tanriverdi, Barut, et al., 2006 #60050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Bayar, Tanriverdi, Barut, et al., 2006 #60050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.63 | 0.24 | 1.65
Bayar, Tanriverdi, Barut, et al., 2006 #60050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 2) Live birth per randomized patient:
Bayar, Tanriverdi, Barut, et al., 2006 #60050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total
Bayar, Tanriverdi, Barut, et al., 2006 #60050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Letrozole | 5 | 20 | 25
Bayar, Tanriverdi, Barut, et al., 2006 #60050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | CC | 7 | 18 | 25
Bayar, Tanriverdi, Barut, et al., 2006 #60050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Total | 12 | 38 | 50
Bayar, Tanriverdi, Barut, et al., 2006 #60050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.71 | 0.26 | 1.95
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | Geographical location: The Netherlands (multicenter study) Study dates: Feb 1998–Oct 2001 Size of population: 168 Number of cycles analyzed: 647 Number of cycles per patient: 3.85 (3.2 for rFSH group, 4.5 for cautery group) Study type: RCT Interventions: Compared the use of electrocautery strategy or recombinant FSH to induce ovulation in CC-resistance POCS pts At time of laparoscopy, randomized to immediate rFSH vs. electrocautery; if no ovulation after 8 weeks or resumption of anovulation after electrocautery, begun on CC (50 mg up to 150 mg); if no ovulation after 150 mg, rFSH begun 45/83 started CC, 21 of these started FSH after failure of CC, 2 immediate rFSH (protocol violation) | Age: Mean (SD): Electrocautery: 28.5 (3.7) RFSH: 28.7 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria:; - Chronic ovulation and PCOS by US; - CC resistance: persistent anovulation after CC 150 mg; Exclusion criteria:; - Other causes of infertility; - Subfertility; - Male factor; - Age > 40; - Tubal occlusion; - Endometriosis stage III or IV | Definition(s) of outcome(s): Ongoing Pregnancy: A viable pregnancy of at least 12 wk Live birth: Yes Multiples: NR Complications: SEE NOTE BELOW Primary outcome of the study is the ongoing pregnancy rate Secondary outcomes were: Ovulation, miscarriage, ectopic pregnancy, multiple pregnancy, and live birth | 1) Ongoing pregnancy rate - compared patients who received electrocautery strategy (patients pregnant from electrocautery and the rest who receive CC and FSH as well) vs. rFSH group: | | | | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | | Preg + | Preg - | Total | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | Electro | 56 | 17 | 83 | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | rFSH | 57 | 28 | 85 | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | | 113 | 45 | 158 | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | Rel risk | 1.14 | 0.94 | 1.39 | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | 2) Live birth rate, electrocautery strategy vs. rFSH: | | | | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | | LB + | LB - | Total | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | Electro | 53 | 30 | 83 | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | rFSH | 51 | 34 | 85 | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | | 104 | 64 | 168 | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | Rel risk | 1.06 | 0.84 | 1.35 | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | 3) Number of miscarriages: | | | | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | Electrocautery: 7 | | | | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | rFSH: 7 | | | | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | 4) Number of multiple births: | | | | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | Electrocautery: 1 | | | | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | rFSH: 9 | | | | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bayram, van Wely, Kaaijk, et al. 2004 #14110 | | | | (RR 0.11; 95% CI 0.01, 0.86) | | | | Comments: Somewhat faster time to pregnancy in rFSH group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
5) Time to 50% pregnancy rate approximately 8 weeks shorter in rFSH group (not significant)
Baysoy, Serdaroglu, Jamal, et al., 2006 #50520 | Geographical location: Istanbul, Turkey Study dates: NR Size of population (no. of patients): 80 Number of cycles analyzed: NR Number of cycles per patient: Not explicitly stated but appears to be 1 cycle per patient Study type: RCT Interventions: Population: Unexplained infertility for 2 years Compare letrozole to HMG with IUI Letrozole: 5 mg/d from day 3–7 of IUI cycle HMG: 75IU on day 3 if age < 30 years or 150 IU for women > 30 years starting day 3 for 5 days | Age: Mean (SD): Letrozole: 27.2 ± 5.5 HMG: 28.1 ± 4.3 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 80 (100%) Inclusion criteria:; - Unexplained infertility: lack of conception after 2 years of unprotected intercourse; - Regular menstrual cycles 26–34 days; - Normal pelvic US; - HSG and/or laparoscopy Showing tubal patency; - Normal thyroid and reproductive hormones; - Normal semen analysis; - At least 1 ovulation induction treatment cycle with IUI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: viable fetus by TVUS Live birth: NR Multiples: Yes Complications: OHSS (no definition provided) | 1) Pregnancy (intention-to-treat): | | | | Comments:; - No intention-to-treat analysis; - Patients not blinded. Specialist performing US and IUI was blinded.; - 2 different HMG doses were used depending on age; no information on how many received each of the HMG doses; Quality assessment: Randomization method: + Blinding: + (specialist was blinded; patients were not blinded) Dropout rate < 20%: - Adequacy of randomization concealment: - (not discussed)
Baysoy, Serdaroglu, Jamal, et al., 2006 #50520 | | | Definition(s) of outcome(s): Pregnancy: viable fetus by TVUS Live birth: NR Multiples: Yes Complications: OHSS (no definition provided) | | Preg + | Preg -
Baysoy, Serdaroglu, Jamal, et al., 2006 #50520 | | | Definition(s) of outcome(s): Pregnancy: viable fetus by TVUS Live birth: NR Multiples: Yes Complications: OHSS (no definition provided) | Letrozole | 7 | 33 | 40
Baysoy, Serdaroglu, Jamal, et al., 2006 #50520 | | | Definition(s) of outcome(s): Pregnancy: viable fetus by TVUS Live birth: NR Multiples: Yes Complications: OHSS (no definition provided) | HMG | 6 | 34 | 40
Baysoy, Serdaroglu, Jamal, et al., 2006 #50520 | | | Definition(s) of outcome(s): Pregnancy: viable fetus by TVUS Live birth: NR Multiples: Yes Complications: OHSS (no definition provided) | | 13 | 67 | 80
Baysoy, Serdaroglu, Jamal, et al., 2006 #50520 | | | Definition(s) of outcome(s): Pregnancy: viable fetus by TVUS Live birth: NR Multiples: Yes Complications: OHSS (no definition provided) | | | Lower 95% CI | Upper 95 % CI
Baysoy, Serdaroglu, Jamal, et al., 2006 #50520 | | | Definition(s) of outcome(s): Pregnancy: viable fetus by TVUS Live birth: NR Multiples: Yes Complications: OHSS (no definition provided) | Rel risk | 1.17 | 0.43 | 3.17
Baysoy, Serdaroglu, Jamal, et al., 2006 #50520 | | | Definition(s) of outcome(s): Pregnancy: viable fetus by TVUS Live birth: NR Multiples: Yes Complications: OHSS (no definition provided) | 2) Multiple gestation (intention-to-treat):
Baysoy, Serdaroglu, Jamal, et al., 2006 #50520 | | | Definition(s) of outcome(s): Pregnancy: viable fetus by TVUS Live birth: NR Multiples: Yes Complications: OHSS (no definition provided) | | Multi + | Multi +
Baysoy, Serdaroglu, Jamal, et al., 2006 #50520 | | | Definition(s) of outcome(s): Pregnancy: viable fetus by TVUS Live birth: NR Multiples: Yes Complications: OHSS (no definition provided) | Letrozole | 1 | 39 | 40
Baysoy, Serdaroglu, Jamal, et al., 2006 #50520 | | | Definition(s) of outcome(s): Pregnancy: viable fetus by TVUS Live birth: NR Multiples: Yes Complications: OHSS (no definition provided) | HMG | 1 | 39 | 40
Baysoy, Serdaroglu, Jamal, et al., 2006 #50520 | | | Definition(s) of outcome(s): Pregnancy: viable fetus by TVUS Live birth: NR Multiples: Yes Complications: OHSS (no definition provided) | | 2 | 78 | 80
Baysoy, Serdaroglu, Jamal, et al., 2006 #50520 | | | Definition(s) of outcome(s): Pregnancy: viable fetus by TVUS Live birth: NR Multiples: Yes Complications: OHSS (no definition provided) | | | Lower 95% CI | Upper 95% CI
Baysoy, Serdaroglu, Jamal, et al., 2006 #50520 | | | Definition(s) of outcome(s): Pregnancy: viable fetus by TVUS Live birth: NR Multiples: Yes Complications: OHSS (no definition provided) | Rel risk | 1.00 | 0.06 | 15.44
3) 1 case of moderate OHSS in the HMG group
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | Geographical location: Los Angeles, LA Study dates: Aug 1997–Nov 1999 Size of population: 86 (96 randomized) Number of cycles analyzed: 204 Number of cycles per patient: 2.37 Study type: RCT Interventions: Compared Tamoxifen to Clomid Tamoxifen dosage started from 20 mg D5–9. If pts were not ovulated, the dose will increase to 40, and 60 mg. Clomid doses started at 50 mg, up to 150 mg D5–9. Population: Unexplained infertility | Age: Mean (SD):; - TMX:26.6 (4.2); - CC: 26.5 (4.4); Median: NR Range: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: NR Endometriosis: NR Male factor: NR Tubal factor: NR PCOS: NR Other (anovulation): 100% Inclusion criteria:; - Normal SA; - Normal pelvic anatomy; - Evidence of tubal patency; Exclusion criteria:; - Abnormal SA; - Tubal blockage; - Age>40; - Evidence of uterine fibroid; - FSH>20; - P4 > 3 ng/ml; - Hyper- or hypothyroidism; - Hyperprolactinemia; - Hepatic or renal disease; - History of exposure to any ovulation induction medication.; - Any contraindication of using these 2 agents | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | 1) Cumulative pregnancy rate: | | | | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | | Out + | Out - | Total | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | TMX | 10 | 36 | 46 | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | CC | 6 | 34 | 40 | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | Total | 16 | 70 | 86 | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.45 | 0.58 | 3.63 | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | 2) Cumulative clinical pregnancy: | | | | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | | Out + | Out - | Total | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | TMX | 9 | 37 | 46 | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | CC | 6 | 34 | 40 | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | Total | 15 | 71 | 86 | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.30 | 0.51 | 3.35 | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | 3) 26 out of 46 patients using TMX ovulated (vs. 30/40 in CC group). | | | | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | 4) Cycles per patient: | | | | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Boostanfar, Jain, Mishell Jr., et al., 2001 #5300 | | | Definition(s) of outcome(s): Pregnancy: NR (the paper did, however, state the outcome of all pregnancies) Live birth: NR Multiples: NR Complications: NR | TMX: 2.46 | | | | Comments:; - Pregnancy was not a primary outcome; - Primary outcome is ovulation; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
CC: 2.28
Branigan and Estes, 2003 #16410 | Geographical location: Bellingham, WA Study dates: NR Size of population: 48 Number of cycles analyzed: 89 Number of cycles per patient: 1.85 Study type: RCT Interventions: Grp 1 Desogen for 42d – 50d. After the withdrawal bleeding, CC 100 mg started on 5d – 9d. Grp 2 No treatment for one or two cycles (38d – 56d), followed by 100 mg of CC on 5d – 9d. hCG 10,000 U was given to all pts who have leading follicle ≥ 20 mm. | Age: Mean (SD): 28.2 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: NR Endometriosis: NR Male factor: 0 Tubal factor: 0 PCOS: NR Other (specify): NR Inclusion criteria:; - Anovulation after CC 150 mg; - Age < 36; - Pt tubes; - Normal fasting serum glucose and insulin level; - Normal prolactin, TSH and FSH; - DHEAS≤200u/ml; - Normoestrogenic; - No contraindication for OC use; - Male partner has normal SA; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + hCG and ultrasound at 7 wk gestation Live birth: NR Multiples: NR Complications: NR | 1) Cumulative pregnancy rate: | | | | Comment:; - Most pts not on OCP were not ovulated with this protocol; - Did use cumulative pregnancy rate over multiple cycles, but CC not continued if no ovulation in first cycle—more than twice as many cycles in OC group; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Branigan and Estes, 2003 #16410 | | | Definition(s) of outcome(s): Pregnancy: + hCG and ultrasound at 7 wk gestation Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Branigan and Estes, 2003 #16410 | | | Definition(s) of outcome(s): Pregnancy: + hCG and ultrasound at 7 wk gestation Live birth: NR Multiples: NR Complications: NR | Study group | 13 | 11 | 24
Branigan and Estes, 2003 #16410 | | | Definition(s) of outcome(s): Pregnancy: + hCG and ultrasound at 7 wk gestation Live birth: NR Multiples: NR Complications: NR | Control | 1 | 23 | 24
Branigan and Estes, 2003 #16410 | | | Definition(s) of outcome(s): Pregnancy: + hCG and ultrasound at 7 wk gestation Live birth: NR Multiples: NR Complications: NR | | 14 | 34 | 48
Branigan and Estes, 2003 #16410 | | | Definition(s) of outcome(s): Pregnancy: + hCG and ultrasound at 7 wk gestation Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 13.00 | 1.84 | 91.71
Branigan and Estes, 2005 #9110 | Geographical location: Bellingham, WA Study dates: NR Size of population (no. of patients): 71 Number of cycles analyzed: NR Number of cycles per patient: NR Study type: RCT Interventions: Population: Previously anovulatory patients on clomiphene citrate (CC) alone Compare whether low-does hCG could be used to complete folliculogenesis and results in successful ovulation and pregnancy Group 1: 100mg CC days 5–9; hCG 10,000 IU IM when lead follicle ≥ 20mm. Group 2: 150mg CC days 5–9 | Age: Mean (SD): Group 1: 34.1 ± 1.1 Group 2: 33.4 + 1.3 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: NR Endometriosis: NR Male factor: 0 Tubal factor: 0 PCOS: NR Other (specify): Inclusion criteria:; 1 Previously documented dominant follicle ≥ 12mm while receiving 100mg CC; 2 Age < 40 years; 3 Normal uterine cavity and patent tubes by either hysterosapingogram or laparoscopy and hysteroscopy; 4 Normal fasting glucose and insulin levels, serum prolactin, TSH, FSH and DHEAS < 200 μg/mL.; 5 Normal semen analysis; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: serum hCG levels and 7-week gestational ultrasounds Live birth: NR Multiples: Yes Complications: NR | 1) Pregnancy (intention to treat): | | | | Comments:; - No discussion regarding blinding; - CC dose was different for Group 1 (100mg) and Group 2 (150mg); Quality assessment: Randomization method: + Blinding: -, not discussed Dropout rate < 20%: + Adequacy of randomization concealment: +
Branigan and Estes, 2005 #9110 | | | Definition(s) of outcome(s): Pregnancy: serum hCG levels and 7-week gestational ultrasounds Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg -
Branigan and Estes, 2005 #9110 | | | Definition(s) of outcome(s): Pregnancy: serum hCG levels and 7-week gestational ultrasounds Live birth: NR Multiples: Yes Complications: NR | CC+hCG | 3 | 32 | 35
Branigan and Estes, 2005 #9110 | | | Definition(s) of outcome(s): Pregnancy: serum hCG levels and 7-week gestational ultrasounds Live birth: NR Multiples: Yes Complications: NR | CC only | 0 | 36 | 36
Branigan and Estes, 2005 #9110 | | | Definition(s) of outcome(s): Pregnancy: serum hCG levels and 7-week gestational ultrasounds Live birth: NR Multiples: Yes Complications: NR | | 3.49 | 68 | 71
Branigan and Estes, 2005 #9110 | | | Definition(s) of outcome(s): Pregnancy: serum hCG levels and 7-week gestational ultrasounds Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Branigan and Estes, 2005 #9110 | | | Definition(s) of outcome(s): Pregnancy: serum hCG levels and 7-week gestational ultrasounds Live birth: NR Multiples: Yes Complications: NR | Rel risk | 6.38 | 0.32 | 126.20
Branigan and Estes, 2005 #9110 | | | Definition(s) of outcome(s): Pregnancy: serum hCG levels and 7-week gestational ultrasounds Live birth: NR Multiples: Yes Complications: NR | 2) No miscarriages
3) No multiple gestations
Checa, Prat, Robles, et al., 2006 #51010 | Geographical location: Barcelona, Spain Study dates: Apr–Sep 2004 Size of population (no. of patients): 67 Number of cycles analyzed: 67 Number of cycles per patient: 1 Study type: RCT Interventions: Population: Infertile patients undergoing controlled ovarian hyperstimulation (COH) and IUI Compare rFSH only to rFSH + Cetrorelix in patient with > 1 and < 4 follicles with diameter ≥ 17 mm rFSH only: rFSH 75–100 IU qd SC starting on day 3. Day 7 and on, dose of rFSH was adjusted based on follicular growth until hCG 250μg sc. IUI 24–48hrs later. rFSH + Cetrorelix: rFSH as above until follicle ≥ 17 mm, then ½ dose of rFSH and Cetrorelix 0.25 mg SC for 2 days | Age: Mean (SD): Cetrorelix: 33 (4.9) 32 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 12 (18%) Female fertility:; - Unexplained infertility: 29 (43%); - Endometriosis: 5 (7%); - Tubal factor: 11 (16%); - Uterine factor: 2 (3%); - Cervical: 8 (12%); - PCOS: 0; Other:; - Primary infertility: 60 (90%); - Secondary infertility: 7 (10%); Inclusion criteria:; - Age 18–39; - Normal menstrual cycle 24–35 days; - FSH ≤ 10 IU/L day 1–3; - Normal uterus and fallopian tubes on HSG; Exclusion criteria:; - PCOS; - Stage III or IV endometriosis | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | 1) Pregnancy: | | | | Comments:; - Regimens were different which can affect blinding; - No allocation concealment; Quality assessment: Randomization method: + Blinding: - (not discussed and regimens were different) Dropout rate < 20%: + Adequacy of randomization concealment: - (not discussed)
Checa, Prat, Robles, et al., 2006 #51010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | Preg + | Preg -
Checa, Prat, Robles, et al., 2006 #51010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | rFSH+ Cetrorelix | 7 | 28 | 35
Checa, Prat, Robles, et al., 2006 #51010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | rFSH | 4 | 28 | 32
Checa, Prat, Robles, et al., 2006 #51010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | 11 | 56 | 67
Checa, Prat, Robles, et al., 2006 #51010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | | Lower 95% CI | Upper 95 % CI
Checa, Prat, Robles, et al., 2006 #51010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | Rel risk | 1.60 | 0.52 | 4.96
Checa, Prat, Robles, et al., 2006 #51010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | 2) Twin gestation:
Checa, Prat, Robles, et al., 2006 #51010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | Multi + | Multi -
Checa, Prat, Robles, et al., 2006 #51010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | rFSH+ Cetrorelix | 3 | 32 | 35
Checa, Prat, Robles, et al., 2006 #51010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | rFSH | 0.49 | 32 | 32
Checa, Prat, Robles, et al., 2006 #51010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | 3.49 | 64 | 67
Checa, Prat, Robles, et al., 2006 #51010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 5.68 | 0.29 | 112.12
Christin-Maitre, Hugues, and Recombinant FSH group, 2003 #16050 | Geographical location: Bondy, France Study dates: NR Size of population (no. of patients): 83 Number of cycles analyzed: 157 Number of cycles per patient: 1.9 Study type: RCT Interventions: Population: CC-resistant PCOS Compare rFSH step-up versus step-down protocol for 3 cycles Step-up: Puregon 50 IU on day 3–5 × 14 days. If no follicle > 9 mm, increase to 75 IU. Further increments by 25 IU weekly up to 100 IU in 1^st^ cycle. In 2^nd^ and 3^rd^ cycle, start dose of 75 IU if no follicular development before dose of 100 IU and maximum of 125 IU for these cycles. Step down: Puregon 100 IU days 3–5. When follicle > 9 mm, dose decreased to 75 IU for 3 days and then to 50 IU until the day prior to hCG. If no follicular development after 5 days, initial dose increased to 150 IU. After follicle development, decrease to 125 IU for 3 days, 100 IU for 3 days and 75 IU until hCG. Both protocols: hCG 5000 IU IM or SC when leading follicle > 18 mm. hCG withheld if ≥ 4 follicles > 16 mm or estradiol level ≥ 1000 pg/ml. | Age: Mean (SD): 28.8 ± 3.2 Step-up: 28.8 ± 3.0 Step down: 28.7 ± 3.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 83 (100%) Inclusion criteria:; - PCOS diagnosed by WHO type II criteria; - CC resistant if failed to ovulate after 3 cycles with CC 100 mg/d for 5 days or failed to conceive after 6 cycles with this treatment; - Oligo/amenorrhea or anovulatory cycles for 2 years; - TVUS > 8 follicles between 2–8 mm with stromal hypertrophy; - Normal prolactin; - Serum FSH < 10 IU/l; - Normal testosterone; - Normal HSG or laparoscopy in past 3 years; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Miscarriage (definition NR) | 1) Pregnancy (intention-to-treat): | | | | Comments:; - Randomization method not described; - Numbered sealed envelopes were used; - No information about blinding; Quality assessment: Randomization method: - (no information provided) Blinding: - (no information provided) Dropout rate < 20%: + Adequacy of randomization concealment: +
Christin-Maitre, Hugues, and Recombinant FSH group, 2003 #16050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Miscarriage (definition NR) | | Preg + | Preg -
Christin-Maitre, Hugues, and Recombinant FSH group, 2003 #16050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Miscarriage (definition NR) | Step up | 17 | 27 | 44
Christin-Maitre, Hugues, and Recombinant FSH group, 2003 #16050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Miscarriage (definition NR) | Step down | 12 | 27 | 39
Christin-Maitre, Hugues, and Recombinant FSH group, 2003 #16050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Miscarriage (definition NR) | | 29 | 54 | 83
Christin-Maitre, Hugues, and Recombinant FSH group, 2003 #16050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Miscarriage (definition NR) | | | Lower 95% CI | Upper 95 % CI
Christin-Maitre, Hugues, and Recombinant FSH group, 2003 #16050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Miscarriage (definition NR) | Rel risk | 1.26 | 0.69 | 2.29
Christin-Maitre, Hugues, and Recombinant FSH group, 2003 #16050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Miscarriage (definition NR) | 2) Multiple gestations (intention-to-treat):
Christin-Maitre, Hugues, and Recombinant FSH group, 2003 #16050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Miscarriage (definition NR) | | Multi + | Multi -
Christin-Maitre, Hugues, and Recombinant FSH group, 2003 #16050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Miscarriage (definition NR) | Step up | 2 | 42 | 44
Christin-Maitre, Hugues, and Recombinant FSH group, 2003 #16050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Miscarriage (definition NR) | Step down | 3 | 36 | 39
Christin-Maitre, Hugues, and Recombinant FSH group, 2003 #16050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Miscarriage (definition NR) | | 5 | 78 | 83
Christin-Maitre, Hugues, and Recombinant FSH group, 2003 #16050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Miscarriage (definition NR) | | | Lower 95% CI | Upper 95 % CI
Christin-Maitre, Hugues, and Recombinant FSH group, 2003 #16050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Miscarriage (definition NR) | Rel risk | 0.59 | 0.10 | 3.35
3) Miscarriage rate: 12.5% step-up vs. 16.7% step-down
Crosignani, Somigliana, and Intrauterine Insemination Study Group, 2007 #51290 | Geographical location: 11 different centers: Amsterdam, Athens, Barcelona, Budapest, Cairo, Hradek Kralove, Lubeck, Milan, Palermo and Prague Study dates: Jan 2004–Oct 2005 Size of population (no. of patients): 299 Number of cycles analyzed: 299 Number of cycles per patient: 1 Study type: RCT Interventions: Population: Unexplained or mild male factor infertility Compare rFSH + Ganirelix vs. rFSH only rFSH only: 50 IU qd starting day 3 rFSH + Ganirelix: rFSH as above and Ganirelix - .25 mg/d when follicle ≥ 13 mm until hCG administered. | Age: Mean (SD): rFSH + Ganirelix: 31.3 ± 3.9 rFSH only: 31.2 ± 3.9 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 209 (70%) Male factor: 90 (30%) Inclusion criteria:; - Age < 38 years; - Primary or secondary infertility for > 2 years; - Regular menstrual cycles; - BMI ≤ 30 kg/m^2^; - Midluteal progesterone > 6ng/ml; - Day 3 FSH < 10 IU/ml; - Normal uterus and fallopian tubes by HSG and/or laparoscopy; - If monolateral tubal occlusion, then normal patent tube by laparoscopy; - Normal semen analysis with > 5 million motile after preparation and 5% normal morphology; - Male subfertility ≤ 20 million/ml concentration, and/or progressive motility < 25% and/or morphology < 9%; - No previous IUI; - Stage I–II endometriosis; Exclusion criteria:; - Stage III–IV endometriosis; - PID | Definition(s) of outcome(s): Pregnancy: US visualization of at least 1 intrauterine gestational sac Ongoing pregnancy: Pregnancy beyond 1^st^ trimester Live birth: NR Multiples: Yes Complications: OHSS definition NR but another reference cited for criteria | 1) Ongoing pregnancy: | | | | Comments:; - Patients and physicians were not blinded; - Intention to treat analysis was performed; Quality assessment: Randomization method: + Blinding: - (patients and physicians not blinded) Dropout rate < 20%: + (12.7% [38/299]) Adequacy of randomization concealment: +
Crosignani, Somigliana, and Intrauterine Insemination Study Group, 2007 #51290 | | | | | Multi + | Multi -
Crosignani, Somigliana, and Intrauterine Insemination Study Group, 2007 #51290 | | | | rFSH + Ganirelix | 15 | 133 | 148
Crosignani, Somigliana, and Intrauterine Insemination Study Group, 2007 #51290 | | | | rFSH | 16 | 135 | 151
Crosignani, Somigliana, and Intrauterine Insemination Study Group, 2007 #51290 | | | | | 31 | 268 | 299
Crosignani, Somigliana, and Intrauterine Insemination Study Group, 2007 #51290 | | | | | | Lower 95% CI | Upper 95 % CI
Crosignani, Somigliana, and Intrauterine Insemination Study Group, 2007 #51290 | | | | Rel risk | 0.96 | 0.49 | 1.86
Crosignani, Somigliana, and Intrauterine Insemination Study Group, 2007 #51290 | | | | 2) Twin gestation:
Crosignani, Somigliana, and Intrauterine Insemination Study Group, 2007 #51290 | | | | | Multi + | Multi -
Crosignani, Somigliana, and Intrauterine Insemination Study Group, 2007 #51290 | | | | rFSH + Ganirelix | 15 | 133 | 148
Crosignani, Somigliana, and Intrauterine Insemination Study Group, 2007 #51290 | | | | rFSH | 3 | 148 | 151
Crosignani, Somigliana, and Intrauterine Insemination Study Group, 2007 #51290 | | | | | 18 | 281 | 299
Crosignani, Somigliana, and Intrauterine Insemination Study Group, 2007 #51290 | | | | | | Lower 95% CI | Upper 95 % CI
Crosignani, Somigliana, and Intrauterine Insemination Study Group, 2007 #51290 | | | | Rel risk | 5.10 | 1.51 | 17.26
3) No cases of OHSS
Dankert, Kremer, Cohlen, et al., 2007 #51370 | Geographical location: Nijmegen, Netherlands Study dates: Jan 2001–Sep 2004 Size of population (no. of patients): 138 Number of cycles analyzed: 406 Number of cycles per patient: 2.94 Study type: RCT Interventions: Population: unexplained and male subfertility Compare CC versus low dose recombinant FSH CC: 100 mg/d on days 3–7. If mono-follicular development, then dose increased by 50 mg in next cycle. If excessive follicle development (≥ 3 follices of > 14 mm), then decreased by 50 mg Low dose rFSH: 75 IU/d SC from cycle day 3 until follicular maturation. If no follicle > 10 mm on day 11, increase to 112.5 IU/d. If mono-follicular development, decrease by 37.5 IU in next cycle. If excessive follicle development (≥ 3 follicles, > 14 mm), then decrease by 37.5 IU. | Age: Mean (SD): Unexplained subfertility: CC: 31.0 rFSH 31.6 Male subfertility: CC: 30.1 rFSH: 31.2 Range: 19.7–38.3 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 68 (49%) Male factor: 70 (51%) Inclusion criteria:; - Primary subfertility for 24 months; - Regular menses cycle 21–35 days; - Laparoscopy and/or HSG to confirm tubal patency; - Unexplained subfertility defined as no abnormality on: ovulation by basal body temp, ultrasound and/or mid-luteal progesterone, post-coital testing, semen analysis and Chlamydia antibody titer; - If + Chlamydia antibodies, then laparoscopy done; Exclusion criteria:; - Age < 18 or > 38; - Anovulation; - Prior assisted reproduction attempts; - Stage III or IV endometriosis; - Contraindication for CC or rFSH; - Resisting ovarian cyst (> 19 mm and 1 > 1 month); - Total motile sperm count < 1 million after semen preparation; - Cancer of ovaries, breast and/or uterus | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | 1) Pregnancy: | | | | Comments:; - Patients not blinded because rFSH SC injection vs. CC which is oral medication; - No information regarding blinding of others in the study; Quality assessment: Randomization method: + Blinding: - (patients not blinded for reasons above; blinding of other individuals not stated) Dropout rate < 20%: + (18% [24/138]) Adequacy of randomization concealment: - (not discussed )
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | | Preg + | Preg -
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | rFSH | 23 | 44 | 67
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | CC | 27 | 44 | 71
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | | 50 | 88 | 138
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | | | Lower 95% CI | Upper 95 % CI
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | Rel risk | 0.90 | 0.58 | 1.41
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | 2) Live birth:
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | | Preg + | Preg -
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | rFSH | 18 | 49 | 67
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | CC | 20 | 51 | 71
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | | 38 | 100 | 138
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | | | Lower 95% CI | Upper 95 % CI
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | Rel risk | 0.95 | 0.55 | 1.64
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | 3) Multiple gestation:
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | | Multi + | Multi -
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | rFSH | 1 | 66 | 67
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | CC | 2 | 69 | 71
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | | 3 | 135 | 138
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | | | Lower 95% CI | Upper 95 % CI
Dankert, Kremer, Cohlen, et al., 2007 #51370 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test; US 7^th^ and 12^th^ week Live birth: Review patient charts or by phone calls to the patient Multiples: On US Complications: NR | Rel risk | 0.53 | 0.05 | 5.71
4) OHSS overall 8.6% (CC: 17/199 cycles = 8.5% vs. rFSH: 18/207 = 8.7%)
Dehbashi, Vafaei, Parsanezhad, et al., 2006 #51490 | Geographical location: Shiraz, Iran Study dates: June 2002 – May 2004 Size of population (no. of patients): 78 Number of cycles analyzed: 149 Number of cycles per patient: Group 1: 71cycles/37 pts = 1.92 Group 2: 78 cycles/41 pts = 1.90 Study type: RCT Interventions: Population: Women with PCOS Group 1: Compare CC 100mg/d on days 1–5 Group 2: CC 100mg/d on days 5–9 | Age: Mean (SD): Group 1: 23.1 ± 3.7 Group 2: 23.0 ± 3.5 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 0 Endometriosis: 0 Male factor: 0 Tubal factor: 0 PCOS: 78 (100%) Other (specify): Inclusion criteria:; - PCOS women defined as anovulatory women with laboratory or clinical evidence of hyperandrogenism but no appreant cause were diagnosed with PCOS.; Exclusion criteria:; - Evaluation included semen analysis, hormonal assays, endometrial biopsy, HSG and any cause of infertility other than PCOS was excluded. | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments:; - No allocation concealment; - No information on blinding; Quality assessment: Randomization method: + Blinding: -, not discussed Dropout rate < 20%: + Adequacy of randomization concealment: -, not discussed
Dehbashi, Vafaei, Parsanezhad, et al., 2006 #51490 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Dehbashi, Vafaei, Parsanezhad, et al., 2006 #51490 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | CC D1–5 | 15 | 22 | 37
Dehbashi, Vafaei, Parsanezhad, et al., 2006 #51490 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | CC D5–9 | 8 | 33 | 41
Dehbashi, Vafaei, Parsanezhad, et al., 2006 #51490 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 23 | 55 | 78
Dehbashi, Vafaei, Parsanezhad, et al., 2006 #51490 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 2.08 | 1.00 | 4.33
Demirol and Gurgan, 2007 #51510 | Geographical location: Ankara, Turkey Study dates: May 2000–May 2004 Size of population (no. of patients): 241 Number of cycles analyzed: 241 Number of cycles per patient: 1 Study type: RCT Interventions: Population: unexplained infertility Compare different gonadotropin preparations: Folitropin α vs. urinary FSH (uFSH) vs. hMG Group 1: rFSH Group 2: uFSH Group 3: hMG For all, day 2–3, 75IU of gonadotrophin if BMI , 25kg/m^2^ or 150 IU if BMI ≥ 25kg/m^2^ | Age: Mean (SD): rFSH: 30.4 ± 2.9 uFSH: 31.5 ± 3.6 hMG: 30.8 ± 3.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 241 (100%) Inclusion criteria:; - Primary infertility > 2 years; - Age between 20–40; - Normal ovulatory cycles; - Patent tubes by HSG or laparoscopy; - Normal sperm count and motility; Exclusion criteria:; - Previous ART; - Previous controlled ovarian stimulation (COS)-IUI cycle; - History of pelvic surgery | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | 1) Pregnancy: | | | | Comments:; - No information regarding blinding; - No adjustment for multiple comparisons; Quality assessment: Randomization method: + Blinding: - (no information) Dropout rate < 20%: + Adequacy of randomization concealment: +
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | rFSH vs. uFSH
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | | Preg + | Preg - | Total
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | uFSH | 11 | 69 | 80
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | rFSH | 21 | 60 | 81
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | Total | 32 | 129 | 161
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | | Value | Lower 95% CI | Upper 95% CI
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | Rel risk | 0.53 | 0.27 | 1.03
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | rFSH vs. hMG
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | | Preg + | Preg - | Total
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | hMG | 10 | 70 | 80
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | rFSH | 21 | 60 | 81
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | Total | 31 | 130 | 161
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | | Value | Lower 95% CI | Upper 95% CI
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | Rel risk | 0.48 | 0.24 | 0.96
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | uFSH vs. hMG
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | | Preg + | Preg -
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | uFSH | 11 | 69 | 80
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | hMG | 10 | 70 | 80
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | | 21 | 139 | 160
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | | | Lower 95% CI | Upper 95 % CI
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | Rel risk | 1.10 | 0.50 | 2.44
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | 3) Multiple pregnancy: no difference
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | rFSH 2/80 = 10%
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | uFSH 0/80 = 0%
Demirol and Gurgan, 2007 #51510 | | | Definition(s) of outcome(s): Pregnancy: US 6 wk after IUI Live birth: NR Multiples: Yes Complications: OHSS (not defined) | hMG 1/80 = 9%
4) No cases of OHSS
Elnashar, Abdelmageed, Fayed, et al., 2006 #51730 | Geographical location: Benha, Egypt Study dates: March – Dec 2004 Size of population (no. of patients): 80 Number of cycles analyzed: 80 as only 1 cycle per patient Number of cycles per patient: 1 Study type: RCT Interventions: Population: All patients had previously received CC and diagnosed with CC resistance (failure of ovulation after 3 cycles of CC reaching 150mg/d dose) Group 1: CC 100mg/d day 3–7 + dexamethzone 2mg/d from day 3–12 Group 2: CC 100mg/d day 3–7 + placebo (folic acid tablets) day 3–12 | Age: Mean (SD): Group 1: 23.4 ± 3.6 Group 2: 25.2 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: Endometriosis: Male factor: Tubal factor: PCOS: 80 (100%) Other (specify): Inclusion criteria:; - PCOS according to Rotterdam criteria; - Age 18–39; - Infertility > 2 years; - Normal serum DHEAS (80–400 μg/dl); - No treatment during prior 2 months; Exclusion criteria:; - Pelvic surgery or infertility factor other than anovulation | Definition(s) of outcome(s): Pregnancy: gestational sac on TVUS 1 week after missed period Live birth: NR Multiples: NR Complications: Side effects Ovulation: disappearance of pre-ovulatory follicle, fluid in the cul-de-sac and/or corpus luteum formation | 1) Pregnancy: | | | | Comments:; - Placebo pill (folic acid) and dexamethasone may have different appearance; Quality assessment: Randomization method: + Blinding: -, placebo pill may look different than dexamethasone pill Dropout rate < 20%: + Adequacy of randomization concealment: +
Elnashar, Abdelmageed, Fayed, et al., 2006 #51730 | | | | | Preg + | Preg -
Elnashar, Abdelmageed, Fayed, et al., 2006 #51730 | | | | CC+ dexameth | 16 | 24 | 40
Elnashar, Abdelmageed, Fayed, et al., 2006 #51730 | | | | CC+ placebo | 2 | 38 | 40
Elnashar, Abdelmageed, Fayed, et al., 2006 #51730 | | | | | 18 | 62 | 80
Elnashar, Abdelmageed, Fayed, et al., 2006 #51730 | | | | | | Lower 95% CI | Upper 95 % CI
Elnashar, Abdelmageed, Fayed, et al., 2006 #51730 | | | | Rel risk | 8.00 | 1.97 | 32.54
2) No side effects for those on dexamethasone
Fancsovits, Toth, Murber, et al., 2005 #10230 | Geographical location: Budapest, Hungary Study dates: March 2000 – July 2003 Size of population (no. of patients): 251 Number of cycles analyzed: 784 Number of cycles per patient: 3.1 Study type: RCT Interventions: Population: Infertile couples undergoing IUI Compare IUI with Gynetics (Belgium) vs Makler cannula (Haifa, Israel) | Age: Mean (SD): Gynetics: 33.1 ± 5.3 Makler 32.2 ± 5.1 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Infertility > 1 year; - Male factor, cervical factor, unexplained infertility or any combination of these; - Ovulatory; - At least 1 open fallopian tube; - ≥ 5 × 10^6^ progressive motile sperm; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test Live birth: NR Multiples: NR Complications: NR | [1) Pregnancy | | | | Comments:; - Patients were blinded; physicians were not as the cannulas are different; - Allocation concealment not discussed; - No intention to treat in paper; unable to calculate ITT results because no information on allocation of the 8 who dropped out; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -, not discussed
Fancsovits, Toth, Murber, et al., 2005 #10230 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Fancsovits, Toth, Murber, et al., 2005 #10230 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test Live birth: NR Multiples: NR Complications: NR | Gynetics | 34 | 88 | 122
Fancsovits, Toth, Murber, et al., 2005 #10230 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test Live birth: NR Multiples: NR Complications: NR | Makler | 32 | 89 | 121
Fancsovits, Toth, Murber, et al., 2005 #10230 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test Live birth: NR Multiples: NR Complications: NR | | 66 | 177 | 243
Fancsovits, Toth, Murber, et al., 2005 #10230 | | | Definition(s) of outcome(s): Pregnancy: + urine pregnancy test Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 1.05 | 0.70 | 1.59
Farquhar, Williamson, Gudex, et al., 2002 #58180 | Geographical location: Auckland, New Zealand Study dates: 1996-1999 Size of population (no. of patients): 50 Number of cycles analyzed: Unclear; 6 months follow-up after diathermy, up to 3 cycles of gonadotropins Number of cycles per patient: > 1.0 Study type: RCT Interventions:; 1) Bilateral laparoscopic diathermy, vs.; 2) 3 cycles gonadotropins | Age: Mean (SD): Drilling: 29.6 (4.7); gonadotropins 29.6 (4.2) Race/ethnicity (n [%]): White: 28 (56%) Maori: 7 (14%) Asian: 10 (20%) Other: 4 (8%) Diagnoses (n [%]): PCOS: 50 (100%) Inclusion criteria: 20–38 years of age, clomiphene citrate resistance (no ovulation after one or more cycles of 150 mg of clomiphene citrate from day 2 to day 6 each month), infertility of ≥ 12 months duration, polycystic ovaries on ultrasound scan according to accepted criteria (10), a body mass index of ≤ 33 kg/m^2^ for women of European descent and of ≤ 35 kg/m^2^ for women of Pacific Island or NZ Maori descent, and normal semen analysis (≥ 20 million per milliliter, ≥ 96% abnormal forms, and ≥ 50% motility) Exclusion criteria: Other known causes of infertility, including male factor infertility or known tubal disease | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | 1) Clinical pregnancy (within 6 months): | | | | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | | Preg + | Pregt - | Total | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | Diathermy | 5 | 24 | 29 | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | Gonadotropins | 5 | 16 | 21 | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | Total | 10 | 40 | 50 | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | Rel risk | 0.72 | 0.24 | 2.19 | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | 2) Live birth (6 months): | | | | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | | Live birth + | Live birth - | Total | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | Diathermy | 4 | 25 | 29 | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | Gonadotropins | 4 | 17 | 21 | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | Total | 8 | 42 | 50 | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | Rel risk | 0.72 | 0.20 | 2.57 | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | 3) Any pregnancy (+ hCG) within 12 months: | | | | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | | Preg + | Preg - | Total | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | Diathermy | 9 | 20 | 29 | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | Gonadotropins | 7 | 14 | 21 | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | Total | 16 | 34 | 50 | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Farquhar, Williamson, Gudex, et al., 2002 #58180 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart on ultrasound Live birth: Birth after 20 weeks Multiples: Yes Complications: NR | Rel risk | 0.93 | 0.41 | 2.10 | Comments: Proportion with BMI ≤ 25 higher in gonadotropin group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
4) No multiples in either group
Fatemi, Kolibianakis, Tournaye, et al., 2003 #58190 | Geographical location: Brussels, Belgium Study dates: Sep 2001–Aug 2002 Size of population (no. of patients): 15 Number of cycles analyzed: 15 Number of cycles per patient: 1.0 Study type: RCT Interventions: Clomiphene 100 mg day 3–7 or letrozole 2.5 mg day 3–7, followed by IUI | Age: Median: Clomiphene 28.2 Letrozole 28.9 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age ≤ 39; - BMI 18–29; - Ovulatory cycles; - Normal semen analysis; - Day 3 FSH ≤ 12; - Normal liver/kidney function; - No history of tubal disease; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + hCG on days 12 and 16 post IUI Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Tournaye, et al., 2003 #58190 | | | Definition(s) of outcome(s): Pregnancy: + hCG on days 12 and 16 post IUI Live birth: NR Multiples: NR Complications: NR | | Out + | Out - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Tournaye, et al., 2003 #58190 | | | Definition(s) of outcome(s): Pregnancy: + hCG on days 12 and 16 post IUI Live birth: NR Multiples: NR Complications: NR | Letrozole | 2 | 5 | 7 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Tournaye, et al., 2003 #58190 | | | Definition(s) of outcome(s): Pregnancy: + hCG on days 12 and 16 post IUI Live birth: NR Multiples: NR Complications: NR | Clomiphene | 3 | 5 | 8 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Tournaye, et al., 2003 #58190 | | | Definition(s) of outcome(s): Pregnancy: + hCG on days 12 and 16 post IUI Live birth: NR Multiples: NR Complications: NR | Total | 5 | 10 | 15 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Tournaye, et al., 2003 #58190 | | | Definition(s) of outcome(s): Pregnancy: + hCG on days 12 and 16 post IUI Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.76 | 0.17 | 3.33
Filicori, Cognigni, Pocognoli, et al., 2003 #15930 | Geographical location: Bologna, Italy Study dates: NR Size of population: 50 Number of cycles analyzed: 50 Number of cycles per patient: 1.0 Study type: RCT Interventions: 150 IU hMG or 150 IU rFSH in COH/IUI cycle | Age: Mean (SD):; - rFSH: 31.9 (0.7); - hMG: 32.6 (0.5); Median: NR Range: 22–38 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 100% Inclusion criteria: Unexplained or mild male factor-related infertility Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy rate: | | | | Comment: Underpowered for pregnancy Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Filicori, Cognigni, Pocognoli, et al., 2003 #15930 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comment: Underpowered for pregnancy Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Filicori, Cognigni, Pocognoli, et al., 2003 #15930 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | rFSH | 4 | 21 | 25 | Comment: Underpowered for pregnancy Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Filicori, Cognigni, Pocognoli, et al., 2003 #15930 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | hMG | 7 | 18 | 25 | Comment: Underpowered for pregnancy Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Filicori, Cognigni, Pocognoli, et al., 2003 #15930 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 11 | 39 | 50 | Comment: Underpowered for pregnancy Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Filicori, Cognigni, Pocognoli, et al., 2003 #15930 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comment: Underpowered for pregnancy Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Filicori, Cognigni, Pocognoli, et al., 2003 #15930 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.57 | 0.19 | 1.71 | Comment: Underpowered for pregnancy Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Duration of treatment and cost significantly lower with hMG
Fleming, Hopkinson, Wallace, et al., 2002 #58210 | Geographical location: Glasgow, UK Study dates: NR Size of population (no. of patients): 94 (42 desired pregnancy) Number of cycles analyzed: 16 weeks of treatment Number of cycles per patient: > 1.0 Study type: RCT Interventions: Metgormin 850 mg BID × 16 weeks vs. placebo | Age: Mean: Metformin: 28.6 Placebo: 29.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100% Inclusion criteria:; - Age <35; - Oligo- (< 8 cycles/year) or amenorrhea; - Polycystic ovaries on transvaginal ultrasound; Exclusion criteria:; - Hyperprolactinemia; - Congenital adrenal hyperplasia; - Abnormal thyroid function | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy (of those seeking pregnancy): | | | | Comments: Not all subjects actively seeking conception Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Fleming, Hopkinson, Wallace, et al., 2002 #58210 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: Not all subjects actively seeking conception Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Fleming, Hopkinson, Wallace, et al., 2002 #58210 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Metformin | 4 | 19 | 23 | Comments: Not all subjects actively seeking conception Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Fleming, Hopkinson, Wallace, et al., 2002 #58210 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Placebo | 1 | 18 | 19 | Comments: Not all subjects actively seeking conception Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Fleming, Hopkinson, Wallace, et al., 2002 #58210 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 5 | 37 | 42 | Comments: Not all subjects actively seeking conception Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Fleming, Hopkinson, Wallace, et al., 2002 #58210 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Not all subjects actively seeking conception Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 3.30 | 0.40 | 27.13
George, George, Chandy, et al., 2007 #52070 | Geographical location: Tamil Nadu and Chennai, India Study dates: NR Size of population (no. of patients): 180 Number of cycles analyzed: NR Number of cycles per patient: NR Study type: RCT Interventions: Population: Women receiving CC for anovulation. CC given days 2–6 with a starting dose 100 mg. Increase 50 mg until a response. Max dose was 200 mg. Compare CC with 5000 IU hCG vs. CC alone Group A: CC and 5,000 IU hCG after follicle reached 18 mm Group B: CC only | Age: Mean (SD): Group A: 24.7 ± 3.5 Group B: 25.1 ± 4.0 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Anovulation 180 (100%) Inclusion criteria:; - All women receiving CC for anovulation, defined as cycle length > 35 days or serum progesterone < 10 ng/ml on day 21 for women with 28-day cycles; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + FH on TVUS at 6–7 wk Live birth: Yes Multiples: NR Complications: Miscarriage | 1) Pregnancy (intention-to-treat): | | | | Comments:; - Blinding issues:; 1 Only Group A received hCG; no placebo in Group B; 2 After 18 mm follicle, Group A advised to have intercourse 36 hrs after hCG vs. Group B advised to have intercourse frequently; - No information about patients who dropped out; - No information about number of cycles total; Quality assessment: Randomization method: Blinding: - (Group A received hCG, Group B did not receive placebo; 2 groups given different instructions for timing of intercourse) Dropout rate < 20%: + Adequacy of randomization concealment: +
George, George, Chandy, et al., 2007 #52070 | | | Definition(s) of outcome(s): Pregnancy: + FH on TVUS at 6–7 wk Live birth: Yes Multiples: NR Complications: Miscarriage | | Preg + | Preg -
George, George, Chandy, et al., 2007 #52070 | | | Definition(s) of outcome(s): Pregnancy: + FH on TVUS at 6–7 wk Live birth: Yes Multiples: NR Complications: Miscarriage | CC+hCG | 10 | 80 | 90
George, George, Chandy, et al., 2007 #52070 | | | Definition(s) of outcome(s): Pregnancy: + FH on TVUS at 6–7 wk Live birth: Yes Multiples: NR Complications: Miscarriage | CC only | 6 | 84 | 90
George, George, Chandy, et al., 2007 #52070 | | | Definition(s) of outcome(s): Pregnancy: + FH on TVUS at 6–7 wk Live birth: Yes Multiples: NR Complications: Miscarriage | | 16 | 164 | 180
George, George, Chandy, et al., 2007 #52070 | | | Definition(s) of outcome(s): Pregnancy: + FH on TVUS at 6–7 wk Live birth: Yes Multiples: NR Complications: Miscarriage | | | Lower 95% CI | Upper 95 % CI
George, George, Chandy, et al., 2007 #52070 | | | Definition(s) of outcome(s): Pregnancy: + FH on TVUS at 6–7 wk Live birth: Yes Multiples: NR Complications: Miscarriage | Rel risk | 1.67 | 0.63 | 4.39
George, George, Chandy, et al., 2007 #52070 | | | Definition(s) of outcome(s): Pregnancy: + FH on TVUS at 6–7 wk Live birth: Yes Multiples: NR Complications: Miscarriage | 2) Live birth (intention-to-treat):
George, George, Chandy, et al., 2007 #52070 | | | Definition(s) of outcome(s): Pregnancy: + FH on TVUS at 6–7 wk Live birth: Yes Multiples: NR Complications: Miscarriage | | Live birth + | Live birth -
George, George, Chandy, et al., 2007 #52070 | | | Definition(s) of outcome(s): Pregnancy: + FH on TVUS at 6–7 wk Live birth: Yes Multiples: NR Complications: Miscarriage | CC+hCG | 8 | 82 | 90
George, George, Chandy, et al., 2007 #52070 | | | Definition(s) of outcome(s): Pregnancy: + FH on TVUS at 6–7 wk Live birth: Yes Multiples: NR Complications: Miscarriage | CC only | 5 | 85 | 90
George, George, Chandy, et al., 2007 #52070 | | | Definition(s) of outcome(s): Pregnancy: + FH on TVUS at 6–7 wk Live birth: Yes Multiples: NR Complications: Miscarriage | | 13 | 167 | 180
George, George, Chandy, et al., 2007 #52070 | | | Definition(s) of outcome(s): Pregnancy: + FH on TVUS at 6–7 wk Live birth: Yes Multiples: NR Complications: Miscarriage | | | Lower 95% CI | Upper 95 % CI
George, George, Chandy, et al., 2007 #52070 | | | Definition(s) of outcome(s): Pregnancy: + FH on TVUS at 6–7 wk Live birth: Yes Multiples: NR Complications: Miscarriage | Rel risk | 1.60 | 0.54 | 4.70
3) No difference in miscarriage rates (1 in CC+hCG group vs. 1 in CC only)
George, George, Irwin, et al., 2003 #17420 | Geographical location: Tamil Nadu, India Study dates: 1999-2001 Size of population: 60 (metformin-30; hMG-30) Number of cycles analyzed: NR Number of cycles per patient: NR Study type: RCT Interventions: Sequential use of metformin for 6 mo followed by Clomid compare to gonadotropin for OI cycle Population: CC-resistance PCOS | Age: Mean (SD): Metformin: 25.1 (3) hMG: 26 (2.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100% Inclusion criteria:; - Tubal factor infertility; - Male factor infertility; - BMI > 35; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 1) Pregnancy rate: | | | | Comments: Cumulative pregnancy rate over multiple cycles Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
George, George, Irwin, et al., 2003 #17420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Out + | Out - | Total | Comments: Cumulative pregnancy rate over multiple cycles Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
George, George, Irwin, et al., 2003 #17420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Metformin | 5 | 25 | 30 | Comments: Cumulative pregnancy rate over multiple cycles Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
George, George, Irwin, et al., 2003 #17420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | hMG | 7 | 23 | 30 | Comments: Cumulative pregnancy rate over multiple cycles Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
George, George, Irwin, et al., 2003 #17420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Total | 12 | 48 | 60 | Comments: Cumulative pregnancy rate over multiple cycles Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
George, George, Irwin, et al., 2003 #17420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Cumulative pregnancy rate over multiple cycles Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
George, George, Irwin, et al., 2003 #17420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.71 | 0.25 | 2.00 | Comments: Cumulative pregnancy rate over multiple cycles Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
George, George, Irwin, et al., 2003 #17420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 2) Live birth rate: | | | | Comments: Cumulative pregnancy rate over multiple cycles Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
George, George, Irwin, et al., 2003 #17420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Out + | Out - | Total | Comments: Cumulative pregnancy rate over multiple cycles Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
George, George, Irwin, et al., 2003 #17420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Metformin | 2 | 28 | 30 | Comments: Cumulative pregnancy rate over multiple cycles Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
George, George, Irwin, et al., 2003 #17420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | hMG | 6 | 24 | 30 | Comments: Cumulative pregnancy rate over multiple cycles Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
George, George, Irwin, et al., 2003 #17420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Total | 8 | 52 | 60 | Comments: Cumulative pregnancy rate over multiple cycles Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
George, George, Irwin, et al., 2003 #17420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Cumulative pregnancy rate over multiple cycles Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.33 | 0.07 | 1.52
Gerli, Casini, Unfer, et al., 2004 #11060 | Geographical location: Perugia and Rome, Italy Study dates: NR Size of population: 170 Number of cycles analyzed: 379 Number of cycles per patient: 2.23 Study type: RCT Interventions: This study compare the outcome of the ovulation induction using uFSH or rFSH in PCOS pts | Age: Mean (SD): uFSH: 28 ± 2.7 rFSH: 29.1 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria: Women with PCOS and a history of 2 yrs of infertility Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Biochemical pregnancy: small or transient increase in b-HCG concentrations Clinical pregnancy: The visualization of an embryo with cardiac activity at 6–7 wk of pregnancy Live birth: NR Multiples: Yes Complications: NR | 1) Clinical pregnancy rate: | | | | Comments: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gerli, Casini, Unfer, et al., 2004 #11060 | | Age: Mean (SD): uFSH: 28 ± 2.7 rFSH: 29.1 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria: Women with PCOS and a history of 2 yrs of infertility Exclusion criteria: NR | | | Preg + | Preg - | Total | Comments: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gerli, Casini, Unfer, et al., 2004 #11060 | | Age: Mean (SD): uFSH: 28 ± 2.7 rFSH: 29.1 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria: Women with PCOS and a history of 2 yrs of infertility Exclusion criteria: NR | | uFSH | 22 | 60 | 82 | Comments: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gerli, Casini, Unfer, et al., 2004 #11060 | | Age: Mean (SD): uFSH: 28 ± 2.7 rFSH: 29.1 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria: Women with PCOS and a history of 2 yrs of infertility Exclusion criteria: NR | | rFSH | 23 | 65 | 88 | Comments: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gerli, Casini, Unfer, et al., 2004 #11060 | | Age: Mean (SD): uFSH: 28 ± 2.7 rFSH: 29.1 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria: Women with PCOS and a history of 2 yrs of infertility Exclusion criteria: NR | | | 45 | 125 | 170 | Comments: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gerli, Casini, Unfer, et al., 2004 #11060 | | Age: Mean (SD): uFSH: 28 ± 2.7 rFSH: 29.1 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria: Women with PCOS and a history of 2 yrs of infertility Exclusion criteria: NR | | | Value | Lower 95% CI | Upper 95% CI | Comments: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gerli, Casini, Unfer, et al., 2004 #11060 | | Age: Mean (SD): uFSH: 28 ± 2.7 rFSH: 29.1 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria: Women with PCOS and a history of 2 yrs of infertility Exclusion criteria: NR | | Rel risk | 1.03 | 0.62 | 1.69 | Comments: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gerli, Casini, Unfer, et al., 2004 #11060 | | Age: Mean (SD): uFSH: 28 ± 2.7 rFSH: 29.1 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria: Women with PCOS and a history of 2 yrs of infertility Exclusion criteria: NR | | 2) Multiple pregnancy: | | | | Comments: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gerli, Casini, Unfer, et al., 2004 #11060 | | Age: Mean (SD): uFSH: 28 ± 2.7 rFSH: 29.1 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria: Women with PCOS and a history of 2 yrs of infertility Exclusion criteria: NR | | | Preg + | Preg - | | Comments: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gerli, Casini, Unfer, et al., 2004 #11060 | | Age: Mean (SD): uFSH: 28 ± 2.7 rFSH: 29.1 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria: Women with PCOS and a history of 2 yrs of infertility Exclusion criteria: NR | | Study group | 3 | 19 | 22 | Comments: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gerli, Casini, Unfer, et al., 2004 #11060 | | Age: Mean (SD): uFSH: 28 ± 2.7 rFSH: 29.1 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria: Women with PCOS and a history of 2 yrs of infertility Exclusion criteria: NR | | Control | 3 | 17 | 20 | Comments: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gerli, Casini, Unfer, et al., 2004 #11060 | | Age: Mean (SD): uFSH: 28 ± 2.7 rFSH: 29.1 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria: Women with PCOS and a history of 2 yrs of infertility Exclusion criteria: NR | | | 6 | 36 | 42 | Comments: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gerli, Casini, Unfer, et al., 2004 #11060 | | Age: Mean (SD): uFSH: 28 ± 2.7 rFSH: 29.1 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria: Women with PCOS and a history of 2 yrs of infertility Exclusion criteria: NR | | | | Lower 95% CI | Upper 95 % CI | Comments: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.91 | 0.21 | 4.00
Gerli, Gholami, Manna, et al., 2000 #58240 | Geographical location: Perugia, Rome, and Naples, Italy Study dates: NR Size of population (no. of patients): 64 Number of cycles analyzed: 64 Number of cycles per patient: 1.0 Study type: RCT Interventions: Clomiphene 100 mg × 5 days (day 3–7) + placebo day 8–12, vs. clomiphene days 3–7 + 0.05 mg ethinyl estradiol days 8–12 | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100% Inclusion criteria:; - Age 25–35; - 2 years infertility Oligo- or amenorrhea with positive bleeding to progesterone withdrawal; - Normal thyroid, prolactin, testosterone; - No prior infertility treatment; Exclusion criteria:; - Abnormal semen analysis; - Tubal or uterine pathology; - BMI > 25 | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on ultrasound at 6–7 weeks, or hCG > 1400 Ongoing: > 20 weeks Live birth: NR Multiples: NR Complications: Miscarriage | 1) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: - Blinding:+ Dropout rate < 20%: + Adequacy of randomization concealment: -
Gerli, Gholami, Manna, et al., 2000 #58240 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on ultrasound at 6–7 weeks, or hCG > 1400 Ongoing: > 20 weeks Live birth: NR Multiples: NR Complications: Miscarriage | | Out + | Out - | Total | Comments: None Quality assessment: Randomization method: - Blinding:+ Dropout rate < 20%: + Adequacy of randomization concealment: -
Gerli, Gholami, Manna, et al., 2000 #58240 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on ultrasound at 6–7 weeks, or hCG > 1400 Ongoing: > 20 weeks Live birth: NR Multiples: NR Complications: Miscarriage | CC + E2 | 12 | 20 | 32 | Comments: None Quality assessment: Randomization method: - Blinding:+ Dropout rate < 20%: + Adequacy of randomization concealment: -
Gerli, Gholami, Manna, et al., 2000 #58240 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on ultrasound at 6–7 weeks, or hCG > 1400 Ongoing: > 20 weeks Live birth: NR Multiples: NR Complications: Miscarriage | CC | 2 | 30 | 32 | Comments: None Quality assessment: Randomization method: - Blinding:+ Dropout rate < 20%: + Adequacy of randomization concealment: -
Gerli, Gholami, Manna, et al., 2000 #58240 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on ultrasound at 6–7 weeks, or hCG > 1400 Ongoing: > 20 weeks Live birth: NR Multiples: NR Complications: Miscarriage | Total | 14 | 50 | 64 | Comments: None Quality assessment: Randomization method: - Blinding:+ Dropout rate < 20%: + Adequacy of randomization concealment: -
Gerli, Gholami, Manna, et al., 2000 #58240 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on ultrasound at 6–7 weeks, or hCG > 1400 Ongoing: > 20 weeks Live birth: NR Multiples: NR Complications: Miscarriage | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: - Blinding:+ Dropout rate < 20%: + Adequacy of randomization concealment: -
Gerli, Gholami, Manna, et al., 2000 #58240 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on ultrasound at 6–7 weeks, or hCG > 1400 Ongoing: > 20 weeks Live birth: NR Multiples: NR Complications: Miscarriage | Rel risk | 6.00 | 1.46 | 24.69 | Comments: None Quality assessment: Randomization method: - Blinding:+ Dropout rate < 20%: + Adequacy of randomization concealment: -
Gerli, Gholami, Manna, et al., 2000 #58240 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on ultrasound at 6–7 weeks, or hCG > 1400 Ongoing: > 20 weeks Live birth: NR Multiples: NR Complications: Miscarriage | 2) Miscarriage: | | | | Comments: None Quality assessment: Randomization method: - Blinding:+ Dropout rate < 20%: + Adequacy of randomization concealment: -
Gerli, Gholami, Manna, et al., 2000 #58240 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on ultrasound at 6–7 weeks, or hCG > 1400 Ongoing: > 20 weeks Live birth: NR Multiples: NR Complications: Miscarriage | | Out + | Out - | Total | Comments: None Quality assessment: Randomization method: - Blinding:+ Dropout rate < 20%: + Adequacy of randomization concealment: -
Gerli, Gholami, Manna, et al., 2000 #58240 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on ultrasound at 6–7 weeks, or hCG > 1400 Ongoing: > 20 weeks Live birth: NR Multiples: NR Complications: Miscarriage | CC + E2 | 2 | 30 | 32 | Comments: None Quality assessment: Randomization method: - Blinding:+ Dropout rate < 20%: + Adequacy of randomization concealment: -
Gerli, Gholami, Manna, et al., 2000 #58240 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on ultrasound at 6–7 weeks, or hCG > 1400 Ongoing: > 20 weeks Live birth: NR Multiples: NR Complications: Miscarriage | CC | 6 | 26 | 32 | Comments: None Quality assessment: Randomization method: - Blinding:+ Dropout rate < 20%: + Adequacy of randomization concealment: -
Gerli, Gholami, Manna, et al., 2000 #58240 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on ultrasound at 6–7 weeks, or hCG > 1400 Ongoing: > 20 weeks Live birth: NR Multiples: NR Complications: Miscarriage | Total | 8 | 56 | 64 | Comments: None Quality assessment: Randomization method: - Blinding:+ Dropout rate < 20%: + Adequacy of randomization concealment: -
Gerli, Gholami, Manna, et al., 2000 #58240 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on ultrasound at 6–7 weeks, or hCG > 1400 Ongoing: > 20 weeks Live birth: NR Multiples: NR Complications: Miscarriage | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: - Blinding:+ Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.33 | 0.07 | 1.53
Ghazeeri. Kutteh, Bryer-Ash, et al., 2003 #17290 | Geographical location: Memphis, Tennessee Study dates: NR Size of population (no. of patients): 25 Number of cycles analyzed: NR Number of cycles per patient: NR Study type: RCT Interventions: Population: CC-resistant overweight and obese women with PCOS Compare rosiglitazone with placebo to rosiglitazone with CC Group 1: Rosiglitazone 4 mg bid with placebo on days 5–9 Group 2: Rosiglitzaone 4 mg bid with CC on days 5–9 | Age: Mean (SD): Group 1: 28.7 ± 3.5 Group 2: 28.7 ± 4.1 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 25 (100%) Inclusion criteria:; - PCOS diagnosed by:; 1 anovulation with mid-luteal progesterone < 5 mg/ml; 2 History of oligomenorrhea with no menses in last 60 days; 3 + progestin withdrawal test; 4 self-reported hirsutism or total testosterone > 65 ng/dl; - Ages 18–40; - BMI > 26 kg/m^2^; - Failure to ovulate with 150 mg/d CC; Exclusion criteria:; - Diabetes or fasting glucose > 125 mg/dL; - CAH or fasting serum 17αOHP > 200 ng/dL; - Thyroid disease; - Hyperprolactinemia; - Congestive heart failure; - Hypertension; - Hepatic or renal disease; - Ovulation induction agent or oral hypoglycemic agent within 30 days | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments:; - Randomization method and allocation concealment were well described; - Investigators, study personnel and patients were blinded; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ghazeeri. Kutteh, Bryer-Ash, et al., 2003 #17290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Ghazeeri. Kutteh, Bryer-Ash, et al., 2003 #17290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rosi + CC | 2 | 11 | 13
Ghazeeri. Kutteh, Bryer-Ash, et al., 2003 #17290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rosi + placebo | 1 | 11 | 12
Ghazeeri. Kutteh, Bryer-Ash, et al., 2003 #17290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | 3 | 22 | 25
Ghazeeri. Kutteh, Bryer-Ash, et al., 2003 #17290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Ghazeeri. Kutteh, Bryer-Ash, et al., 2003 #17290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.85 | 0.19 | 17.85
Ghazeeri. Kutteh, Bryer-Ash, et al., 2003 #17290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 2) Live birth:
Ghazeeri. Kutteh, Bryer-Ash, et al., 2003 #17290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Live birth + | Live birth -
Ghazeeri. Kutteh, Bryer-Ash, et al., 2003 #17290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rosi + CC | 1 | 12 | 13
Ghazeeri. Kutteh, Bryer-Ash, et al., 2003 #17290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rosi + placebo | 1 | 11 | 12
Ghazeeri. Kutteh, Bryer-Ash, et al., 2003 #17290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | 2 | 23 | 25
Ghazeeri. Kutteh, Bryer-Ash, et al., 2003 #17290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 0.92 | 0.06 | 13.18
Gomes, Vieira, Moura, et al., 2007 #52230 | Geographical location: Sao Paulo, Brazil Study dates: NR Size of population (no. of patients): 51 Number of cycles analyzed: 51 Number of cycles per patient: 1 Study type: RCT Interventions: Population: Patients undergoing controlled ovarian stimulation Compare hCG vs. hMG vs. rFSH in late stage of follicular development All patients: OCPs 1^st^ day of previous menses until 5 days prior to stimulation. Leuprolide acetate 0.5 mg/d started 10 days before induction and continued until day before hCG injection. rFSH 200 IU daily sq until dominant follicle 12–13 mm. Then divided into groups. hCG: 200 IU IM daily until follicles 18–19 mm hMG: 225 IU IM daily rFSH: 200 IU SC daily | Age: Mean (SD): hCG: 30.1 hMG: 29.4 rFSH: 29.0 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 39 (76%) Tubal factor: 7 (14%) Other: “Association”: 5 (10%) Inclusion criteria:; - Ages 25–35; - Regular menstrual cycles; - Normal BMI (20–25 kg/m^2^); - Tubal factor or unexplained or moderate to severe male factor infertility (less than 5 million motile, progressive and normal sperm after washing).; Exclusion criteria:; - PCOS; - FSH > 10 IU/mL during early follicular phase; - Endometriosis; - Uterine myomas; - Use of injectable hormonal contraceptive up to 6 months before stimulation; - Poor ovarian response to controlled ovarian stimulation in past; - Uterine alterations or absence of 1 ovary | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | 1) Pregnancy: | | | | Comments: No information about allocation concealment or blinding Quality assessment: Randomization method: + Blinding: - (no information) Dropout rate < 20%: + Adequacy of randomization concealment: - (not discussed)
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | hCG vs. rFSH
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | | Preg + | Preg -
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | hCG | 9 | 8 | 17
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | rFSH | 4 | 13 | 17
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | | 13 | 21 | 34
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | | | Lower 95% CI | Upper 95 % CI
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | Rel risk | 2.25 | 0.86 | 5.92
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | hMG vs. rFSH
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | | Preg + | Preg -
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | hMG | 5 | 12 | 17
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | rFSH | 4 | 13 | 17
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | | 9 | 25 | 34
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | | | Lower 95% CI | Upper 95 % CI
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | Rel risk | 1.25 | 0.40 | 3.87
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | hCG vs. hMG
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | | Preg + | Preg -
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | hCG | 9 | 8 | 17
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | hMG | 5 | 12 | 17
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | | 14 | 20 | 34
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | | | Lower 95% CI | Upper 95 % CI
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | Rel risk | 1.80 | 0.76 | 4.26
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | 3) Multiple gestations:
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | hCG: 3/17 (18%)
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | hMG: 3/17 (18%)
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | rFSH: 0/17 (0%)
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | 4) Abortion:
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | hCG: 3/9 (33%)
Gomes, Vieira, Moura, et al., 2007 #52230 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: Abortion | hMG: 0/5 (0%)
rFSH: 1/4 (25%)
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | Geographical location: Madrid, Spain Study dates: 1/03–6/03 Size of population: 82 Number of cycles analyzed: 82 Number of cycles per patient: 1.00 Study type: RCT Interventions: The aim of this study is to assess the efficacy of a GnRH antagonist in IUI cycles. Control: rFSH Alone Experiment grp : rFSH+ GnRH antagonist (Ganirelix) | Age: Mean (SD): GnRHa: 33.9 (2.6) Control: 32.05 (3.3) Median: NR Range: 18–38 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: GnRHa: 30 (75) Control: 28 (67) Endometriosis: 0 Male factor: 0 Tubal factor: 0 PCOS: 0 Other (specify): Anovulation GnRHa: 10 (25) Control: 14 (33) Inclusion criteria:; - age 18–38; - Regular period; - Infertility lasting > or= 12 mos; - Normal prolactin; - Normal thyroid function tests; - Normal uterine cavity; - Bilateral tubal petency; Exclusion criteria:; - FSH > 10; - PCOS | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | 1) Clinical pregnancy rate: | | | | Comment:; - Grp 1 had stat significantly greater # of follicles compared to Grp 2: 2.4 vs. 1.7, p = 0.02; - 1 pt excluded from each grp due to excessive follicle #; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | | Preg + | Preg -
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | Study group | 15 | 25 | 40
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | Control | 6 | 36 | 42
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | | 21 | 61 | 82
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | | | Lower 95% CI | Upper 95 % CI
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | Rel risk | 2.63 | 1.13 | 6.09
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | 2) No miscarriage noted in both groups
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | There is no difference in the Singleton and Multiple pregnancy rate between 2 grps
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | Singleton
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | GnRHa 93% (14/15)
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | Control : 100% (6/6)
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | Multiple pregnancy
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | 1 pt in GnRHa
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | None in Control
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | 2) Multiples:
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | Grp 1: 6.6%
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | Grp 2: 0
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | 3) SAB:
Gomez-Palomares, Julia, Acevedo-Martin, et al., 2005 #9720 | | | Definition(s) of outcome(s): Pregnancy:; - Clinical pregnancy:+ hCG and + heart beat on u/s; - Biochemical pregnancy: + hCG alone; Live birth: NR Multiples: Yes Complications: SAB | Grp 1: 0
Grp 2: 14%
Grigoriou, Makrakis, Konidaris, et al., 2005 #10260 | Geographical location: Athens, Greece Study dates: May 2002–Oct 2003 Size of population (no. of patients): 52 Number of cycles analyzed: 133 Number of cycles per patient: 2.6 Study type: RCT Interventions: Ovarian stimulation was CC days 3–7, hCG 10,000 U when lead follicle ≥18mm. IUI 34–38 hrs after hCG Compare sperm treatment with exogenous platelet - activating factor (PAF) PAF: sperm for IUI treated with PAF (10^-7^ mol/L) for 3 cycles nonPAF: direct swim-up technique for 3 cycles If no pregnancy after first 3 cycles, then cross over design. Only data from 1^st^ 3 cycles presented. | Age: Mean (SD): PAF: 30.6 ± 3.1 NonPAF: 31.8 ± 4.1 Median: NR Range: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Population: Couples with unexplained infertility and candidates for IUI; - Infertility ≥1 year; - Regular menstrual cycles 26–32 days; - Ovulatory basal body temperature chart; - Midluteal serum P levels ≥32ng/ml; - Normal levels of FSH, LH, androstenedione and DHEAS; - Normal prolactin on day 3; - Normal thyroid function tests; - Nonsignificant results from TVUS; - Normal HSG; - Nonsignificant results at laparoscopy; - Normal semen analysis on 2 occasions; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: gestational sac with fetal pole on US Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy (intention to treat): | | | | Comments:; - Patients were crossed over if they failed the 1^st^ assigned treatment after 3 cycles; - Only data from the 1^st^ 3 cycles is presented; - No information regarding blinding; Quality assessment: Randomization method: + Blinding: -, no information Dropout rate < 20%: + Adequacy of randomization concealment: -, not discussed
Grigoriou, Makrakis, Konidaris, et al., 2005 #10260 | | | Definition(s) of outcome(s): Pregnancy: gestational sac with fetal pole on US Live birth: NR Multiples: NR Complications: NR | - Only data from 1^st^ 3 cycles before cross over
Grigoriou, Makrakis, Konidaris, et al., 2005 #10260 | | | Definition(s) of outcome(s): Pregnancy: gestational sac with fetal pole on US Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Grigoriou, Makrakis, Konidaris, et al., 2005 #10260 | | | Definition(s) of outcome(s): Pregnancy: gestational sac with fetal pole on US Live birth: NR Multiples: NR Complications: NR | PAF | 14 | 12 | 26
Grigoriou, Makrakis, Konidaris, et al., 2005 #10260 | | | Definition(s) of outcome(s): Pregnancy: gestational sac with fetal pole on US Live birth: NR Multiples: NR Complications: NR | nonPAF | 6 | 20 | 26
Grigoriou, Makrakis, Konidaris, et al., 2005 #10260 | | | Definition(s) of outcome(s): Pregnancy: gestational sac with fetal pole on US Live birth: NR Multiples: NR Complications: NR | | 20 | 32 | 52
Grigoriou, Makrakis, Konidaris, et al., 2005 #10260 | | | Definition(s) of outcome(s): Pregnancy: gestational sac with fetal pole on US Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 2.33 | 1.06 | 5.13
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | Geographical location: Multicenter Study dates: Mar 1996–May 1999 Size of population: 198 Number of cycles analyzed: 198 Number of cycles per patient: 1.00 Study type: RCT Interventions: Compare the use of recombinant 250 ug hCG (Ovidrel) and 5000 IU of uhCG for surrogate LH surge in COH cycle. COH protocol: rFSH step up protocol. No GnRH agonist used. Each pt either received 2 SQ injections (1 injection of hCG and one injection of placebo to study side effect when criteria met; - One follicle with mean diameter ≥18 mm; - No more 3 follicle with mean diameter ≥16 mm; - No more 4 follicle 11–15 mm; - Estradiol level appropriate for the number of follicles but not higher than 5500 pmol/L (1500 pg/ml); Insemination was via IUI or home intercourse. | Age: Mean (SD): rhCG 29.2 (3.7) uhCG 28.5 (3.5) All 28.8 (3.6) Range: 20–38 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Ovulatory dysfunction 100%: Inclusion criteria:; - Infertility due to ovulatory dysfunction; - Spontaneous menses, menses induced by CC therapy, or a positive progesterone-withdrawal bleeding within the previous year; - No more than 10 previous cycles of gonadotropins or clomiphene citrate, the last cycle of which should not have been within 2 months of the study; - Acceptable pretreatment hormone levels in blood samples withdrawn within 3 months of the start of treatment, that is:; (a) FSH (≥ 3 IU/L and ≤ 12 IU/L); (b) Progesterone< 10 nmole/L); (c) Prolactin (<800 mlIU/L); (d) Testosterone <6.0 nmol.L); (e) DHEAS <20.0 umol/L; (f) 17 OHP (<14.4 nmol/L); (g) TSH (0.3–4.1 mIUlL); (h) Free thyroxine 11–24 pmol/L; - Two patent tubes; - Normal uterine cavity; - BMI ≥18 and ≤ 35; - Male partner with SA within acceptable value within the past 6 mo:; (a) .10 M/ml; (b) 25% with linear progression and normal morphology according to the local laboratory; (c) No significant infection within the last 6 mo; Exclusion criteria:; - Clinically significant condition; - Positive HIV serology; - Positive Hep B surface antigen serology, unless vaccinated; - Abnormal gynecological bleeding of unknown origin; - History of severe OHSS; - Active substance abuse | Definition(s) of outcome(s): Pregnancy and clinical pregnancy: Not defined Live birth: Yes Multiples: NR Complications: Local adverse reactions (redness, pain, itching, swelling, bruising) OHSS (not defined) | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | rhCG | 26 | 73 | 99 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | uhCG | 31 | 68 | 99 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | | 57 | 141 | 198 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | Rel risk | 0.84 | 0.54 | 1.30 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | 2) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | rhCG | 22 | 77 | 99 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | uhCGl | 29 | 70 | 99 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | | 51 | 147 | 198 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | Rel risk | 0.76 | 0.47 | 1.22 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | 3) Live birth rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | | LB + | LB - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | rhCG | 14 | 85 | 99 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | uhCG | 20 | 79 | 99 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | | 34 | 164 | 198 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | Rel risk | 0.70 | 0.38 | 1.31 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | 4) Local side effects: Pts with uhCG reports more side effects than rhCG (0.0002). When looking into the detailed of the local side effect, the only thing that has statistically between the 2 grps is redness (p < 0.0001) | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
International Recombinant Human Chorionic Gonadotropin Study Group, 2001 #5150 | | | | 5) There were 3 OHSS reported in rhCG grp (all are moderate OHSS). None were reported in uhCG group. | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
6) Pts in rhCG grp had overall higher luteal phase progesterone when compared to uhCG
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | Geographical location: Uppsala, Sweden Study dates: NR Size of population: 161 Number of cycles analyzed: 161 Number of cycles per patient: 1.00 Study type: RCT Interventions:; 1) study the usage of GnRH agonist during hMG treatment VS. hMG alone in IUI cycle; 2) Study the efficacy of one vs. two insemination per cycle; GnRH agonist used: Busereline 300 ug intranasal q 4–6 hr., start on the fist day of the menstrual period. hMG started with E2 less than 100 pmol/L | Age: Mean (SD): NR GnRHa + hMG:31.9 (0.4) hMG 32.4 (0.4) one IUI:32.1 (0.4) two IUI: 32.4 (0.4) Median: NR Range: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 88 Endometriosis: 39 Male factor: 21 Tubal factor: 0 PCOS: 0 Other (specify): Cervical factor 24 Inclusion criteria:; - h/o failed 1 cycle of CC or hMG combined with IUI or home intercourse; - non-tubal infertility; - normal ovulatory function; Exclusion criteria:; - cycle length >35 days | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | 1) GnRHa+hMG vs. hMG: pregnancy rate: | | | | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | | Out + | Out - | Total | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | GNRha+ hMG | 10 | 71 | 81 | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | Hmg | 7 | 63 | 80 | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | Total | 17 | 134 | 151 | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | | Value | Lower 95% CI | Upper 95% CI | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | Rel risk | 1.23 | 0.50 | 3.07 | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | 2) 2 vs. one IUI, pregnancy rate: | | | | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | | Out + | Out - | Total | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | 2 IUI | 6 | 59 | 65 | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | one IUI | 10 | 77 | 87 | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | Total | 16 | 136 | 152 | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | | Value | Lower 95% CI | Upper 95% CI | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | Rel risk | 0.80 | 0.31 | 2.10 | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | 3) GnRHa+hMG vs. hMG: live birth rate: | | | | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | | Out + | Out - | Total | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | GNRha+ hMG | 8 | 73 | 81 | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | hMG | 7 | 63 | 80 | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | Total | 15 | 136 | 151 | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | | Value | Lower 95% CI | Upper 95% CI | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Karlstrom, Bergh, and Lundkvist, 2000 #8810 | | | Definition(s) of outcome(s): Pregnancy: u/s showed gestational sac Live birth: Yes Multiples: Yes Complications: Miscarriage | Rel risk | 0.99 | 0.38 | 2.59 | Comments: 2×2 factorial design Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
4) No difference in multiple gestation on miscarriage rate
Kocak, Caliskin, Simsir, et al., 2002 #58300 | Geographical location: Ankara, Turkey Study dates: NR Size of population (no. of patients): 56 Number of cycles analyzed: 112 Number of cycles per patient: 2 Study type: RCT? Interventions: 1 cycle of metformin or placebo, followed by 2^nd^ cycle of metformin or placebo + 100 mg CC days 3–7 | Age: Mean (SD): Metformin: 26.2 ± 3.7 Placebo: 27.1 ± 4.5 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 56 (100%) Inclusion criteria:; - Clomiphene resistance: failure to have an ovarian response for three consecutive cycles on transvaginal ultrasonographic examination with concomitant failure of E2 levels to increase after treatment with CC, 150 mg daily for 5 days; - Oligomenorrhea (< 6 menstrual periods in the preceding year) with hirsutism, hyperandrogenemia, or presence of multiple subcapsular follicles by vaginal; - Ultrasound during the first 3 days of spontaneous menstrual bleeding; Exclusion criteria:; - Abnormal endocrine profile, pelvic anatomy; - Diabetes; - Use of OCPs or anti-diabetics within preceding 2 months | Definition(s) of outcome(s): Pregnancy: “confirmed by ultrasound” Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: Unclear whether true RCT; + allocation concealment, but based on admission numbers, not true randomization Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Kocak, Caliskin, Simsir, et al., 2002 #58300 | | | Definition(s) of outcome(s): Pregnancy: “confirmed by ultrasound” Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total
Kocak, Caliskin, Simsir, et al., 2002 #58300 | | | Definition(s) of outcome(s): Pregnancy: “confirmed by ultrasound” Live birth: NR Multiples: NR Complications: NR | Metformin | 4 | 24 | 28
Kocak, Caliskin, Simsir, et al., 2002 #58300 | | | Definition(s) of outcome(s): Pregnancy: “confirmed by ultrasound” Live birth: NR Multiples: NR Complications: NR | Placebo | 0 | 28 | 28
Kocak, Caliskin, Simsir, et al., 2002 #58300 | | | Definition(s) of outcome(s): Pregnancy: “confirmed by ultrasound” Live birth: NR Multiples: NR Complications: NR | Total | 4 | 52 | 56
Kocak, Caliskin, Simsir, et al., 2002 #58300 | | | Definition(s) of outcome(s): Pregnancy: “confirmed by ultrasound” Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 9.00 | 0.51 | 159.70
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | Geographical location: Ontario, Canada Study dates: June 2000–Jan 2002 Size of population (no. of patients): 161 Number of cycles analyzed: 1 cycle per patient but only 118 completed the trial Number of cycles per patient: As above Study type: RCT Interventions: Population: Anovulatory or oligoovulatory women Compare two low-dose rFSH step-up protocols Both start with 50 IU for 7 days. At weekly intervals, daily dose increased by 25 IU for one group vs. 50 IU for the other if no follicle at least 12 mm. Treatment continued until 1 follicle ≥ 18 mm, then hCG 10,000 IU SC or IM. | Age: Mean (SD): 25 IU: 29.5 ± 4.0 50 IU: 29.9 ± 4.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Other (specify): 158 (100%) Anovulatory or oligoovulatory women Inclusion criteria:; - WHO group II infertility; anovulatory or oligoovulatory; - Infertile > 1 year; - No ovulation or conception during at least 3 preceding CC cycles; - No CC or gonadotropins within 30 days prior to study treatment; - Age 18–39; - BMI 18–33 kg/m^2^; - Normal uterine cavity by hysteroscopy, HSG or sonohyst within 3 years; - Normal testosterone; - Normal semen analysis; Exclusion criteria:; - Pregnant or lactating; - Prior hospitalization for OHSS; - Untreated hyperprolactinemia; - Tumors of ovary, breast, uterus, pituitary or hypothalamus; - GYN condition incompatible with pregnancy (severe fibroids or sexual organ malformation); - Undiagnosed vaginal bleeding; - Primary ovarian failure; - Current or recent drug or EtOH abuse | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | 1) Pregnancy (intention-to-treat): | | | | Comments:; - Patients not blinded as they injected themselves; - Drop-out 27% (43/161); - No information about allocation concealment; Quality assessment: Randomization method: + Blinding: - (patients not blinded and no additional information about blinding of others) Dropout rate < 20%: – (27%) Adequacy of randomization concealment: - (not discussed)
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | | Preg + | Preg -
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | 50 IU | 10 | 68 | 78
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | 25 IU | 16 | 67 | 83
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | | 26 | 135 | 161
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | | | Lower 95% CI | Upper 95 % CI
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | Rel risk | 0.67 | 0.32 | 1.38
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | 2) Multiple gestations (intention-to-treat):
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | | Multi + | Multi -
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | 50 IU | 0 | 78 | 78
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | 25 IU | 2 | 81 | 83
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | | 2.49 | 159 | 161
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | | | Lower 95% CI | Upper 95 % CI
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | Rel risk | 0.26 | 0.01 | 5.80
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | 3) Ovarian hyper-response (intention-to-treat):
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | | OHSS + | OHSS -
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | 50 IU | 16 | 62 | 78
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | 25 IU | 4 | 79 | 83
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | | 20 | 141 | 161
Leader and Monofollicular Ovulation Induction Study Group, 2006 #53480 | | | Definition(s) of outcome(s): Pregnancy: + hCG and US Live birth: NR Multiples: Yes Complications: OHSS (definition NR) | | | Lower 95% CI | Upper 95 % CI
Rel risk | 4.26 | 1.49 | 12.18
Legro, Barnhart, Schlaff, et al., 2007 #42670 | Geographical location: 12 centers in the U.S. including Hershey, PA; Durham, NC; Houston, TX; Detroit, MI; Dallas, TX; Denver, CO; Philadelphia, PA; Newark, NJ; Palo Alto, CA; Birmingham, AL; Richmond, VA; and Pittsburgh, PA Study dates: NR Size of population: 626 infertile women Number of cycles analyzed: 2925 Number of cycles per patient: 4.67 Study type: RCT Interventions: Metformin extended-release (Glucophage XR) 1000 mg bid × 6 cycles or 30 wk Clomiphene citrate 50 mg × 5 d beginning on day 3 of menses (dose maintained if adequate ovulation was documented; in non- or poor responders, dose increased to 100 mg/d and then 150 mg/d) Metformin + clomiphene Pt w/o recent menses had withdrawal bleed induced with PO medroxyprogesterone acetate | Age: Mean (SD): 28.1 (4.0) Race/ethnicity (n [%]): White 435 (69.5%) Black 109 (17.4%) Asian 17 (2.7%) Other 72 (11.5%) Diagnoses (n [%]): PCOS: 100% Inclusion criteria: PCOS based on unexplained hyperandrogenic chronic anovulation, using the 1990 NIH criteria: oligomenorrhea with a history of ≤ 8 spontaneous menses/yr and hyperandrogenemia based on an elevated testosterone level documented within 1 yr; with normal uterine cavity; ≥ 1 pt fallopian tube; partner with ≥ 20 × 10^6^/mL sperm concentration Exclusion criteria:; - Cause of infertility other than PCOS (PRL excess, thyroid disease, and nonclassic congenital adrenal hyperplasia); - Poor health; - Any major medical illness | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | 1) Rate of live birth: | | | | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: - (dropout rates were 26% C; 35% M; 23% C+M; despite the fact that dropout rates exceeded 20%, they were fairly similarly high between groups) Adequacy of randomization concealment: + Also Q1b
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Metformin vs. no metformin (clomiphene or combination):
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | | Out + | Out - | Total
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Exp + | 15 | 193 | 208
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Exp - | 103 | 315 | 418
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Total | 118 | 508 | 626
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | | Value | Lower 95% CI | Upper 95% CI
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Rel risk | 0.29 | 0.17 | 0.49
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Clomiphene vs. no clomiphene (metformin or combination):
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | | Out + | Out - | Total
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Exp + | 47 | 162 | 209
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Exp - | 71 | 346 | 417
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Total | 118 | 508 | 626
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | | Value | Lower 95% CI | Upper 95% CI
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Rel risk | 1.32 | 0.95 | 1.84
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | 2) Rate of singleton pregnancy:
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Metformin vs. no metformin (clomiphene or combination):
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | | Out + | Out - | Total
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Exp + | 18 | 190 | 208
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Exp - | 110 | 308 | 418
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Total | 128 | 498 | 626
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | | Value | Lower 95% CI | Upper 95% CI
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Rel risk | 0.33 | 0.21 | 0.53
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Clomiphene vs. no clomiphene (metformin or combination):
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | | Out + | Out - | Total
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Exp + | 47 | 162 | 209
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Exp - | 81 | 336 | 417
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Total | 128 | 498 | 626
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | | Value | Lower 95% CI | Upper 95% CI
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | Rel risk | 1.16 | 0.84 | 1.59
Legro, Barnhart, Schlaff, et al., 2007 #42670 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: Yes Complications: Various (see at right) (Also NR in methods paper, Legro RS et al, [underlined: Fertility and Sterility], 2006) | 3) Multiple gestation -observed only with clomiphene-treated pts - twins were observed in 2 of 50 pregnancies with clomiphene alone, and 2 of 65 pregnancies with clomiphene + metformin; triplets were observed in 1/50 pregnancies (clomiphene alone)
4) Complications - no significant differences between treatment grps were reported for pregnancy losses (among pts who conceived), 1^st^ trimester losses, ectopic pregnancy, or 2^nd^–3^rd^ trimester losses.
Lewis, Queenan, Hoeger, et al., 2006 #53610 | Geographical location: Brockport, New York Study dates: NR Size of population (no. of patients): 150 Number of cycles analyzed: NR Number of cycles per patient: more than 1 cycle per patient but actual number of cycles was NR Study type: RCT Interventions: Population: Patients treated with CC 100mg on days 5–9 Compare two different methods of intrauterine insemination (IUI) timing LH surge group: IUI day after home test for LH surge was positive hCG group: hCG 10,000 units when at least 1 follicle 2-mm and endometrial thickness > 8mm; IUI 33–40 hours later | Age: Mean (SD): LH: 33.5 ± 3.9 hCG: 34.0 ± 3.9 Range: 23–42 Race/ethnicity (n [%]): Caucasian 130 (87%) African-American 13 (9%) Hispanic 5 (3%) Asian 2 (1%) Diagnoses (n [%]): Unexplained infertility: 97 (65%) Endometriosis: 14 (9%) Male factor: 19 (13%) Tubal factor: 14 (9%) PCOS: NR Cervical factor 6 (4%) Inclusion criteria:; - Ovulatory patients who had infertility, defined by at least 1 year of unprotected intercourse or 3 failed cycles of donor IUI; - Ovulatory if monthly menses and biphasic basal body temperature charts or a h/o of positive ovulation predictor kids or midluteal serum progesterone in ovulatory range; - At least 1 normal, patent fallopian tube and a functional ipsilateral ovary; Exclusion criteria:; - Elevated FSH on day 3; - Severe endometriosis; - Recurrent pregnancy loss; - Previous use of superovulation and IUI; - Severe male factor infertility (< 4 million motile sperm) | Definition(s) of outcome(s): Pregnancy: rising hCG and then viable when fetal pole with cardiac activity seen on US Live birth: NR Multiples: Yes Complications: NR | 1) Viable pregnancy (intention-to-treat): | | | | Comments:; - Patients and physicians unblended after informed consent and baseline US performed; - No information about allocation concealment; Quality assessment: Randomization method: + Blinding: -, as above, patients an physicians unblended after consent and US performed Dropout rate < 20%: -, overall drop out 31/150 = 20.6%. LH surge 11% vs hCG 31%. Adequacy of randomization concealment: -, not stated
Lewis, Queenan, Hoeger, et al., 2006 #53610 | | | Definition(s) of outcome(s): Pregnancy: rising hCG and then viable when fetal pole with cardiac activity seen on US Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg -
Lewis, Queenan, Hoeger, et al., 2006 #53610 | | | Definition(s) of outcome(s): Pregnancy: rising hCG and then viable when fetal pole with cardiac activity seen on US Live birth: NR Multiples: Yes Complications: NR | hCG | 19 | 56 | 75
Lewis, Queenan, Hoeger, et al., 2006 #53610 | | | Definition(s) of outcome(s): Pregnancy: rising hCG and then viable when fetal pole with cardiac activity seen on US Live birth: NR Multiples: Yes Complications: NR | LH surge | 11 | 64 | 75
Lewis, Queenan, Hoeger, et al., 2006 #53610 | | | Definition(s) of outcome(s): Pregnancy: rising hCG and then viable when fetal pole with cardiac activity seen on US Live birth: NR Multiples: Yes Complications: NR | | 30 | 120 | 150
Lewis, Queenan, Hoeger, et al., 2006 #53610 | | | Definition(s) of outcome(s): Pregnancy: rising hCG and then viable when fetal pole with cardiac activity seen on US Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Lewis, Queenan, Hoeger, et al., 2006 #53610 | | | Definition(s) of outcome(s): Pregnancy: rising hCG and then viable when fetal pole with cardiac activity seen on US Live birth: NR Multiples: Yes Complications: NR | Rel risk | 1.73 | 0.88 | 3.38
Lewis, Queenan, Hoeger, et al., 2006 #53610 | | | Definition(s) of outcome(s): Pregnancy: rising hCG and then viable when fetal pole with cardiac activity seen on US Live birth: NR Multiples: Yes Complications: NR | 2) Multiple gestation (intention-to-treat):
Lewis, Queenan, Hoeger, et al., 2006 #53610 | | | Definition(s) of outcome(s): Pregnancy: rising hCG and then viable when fetal pole with cardiac activity seen on US Live birth: NR Multiples: Yes Complications: NR | | Multi + | Multi -
Lewis, Queenan, Hoeger, et al., 2006 #53610 | | | Definition(s) of outcome(s): Pregnancy: rising hCG and then viable when fetal pole with cardiac activity seen on US Live birth: NR Multiples: Yes Complications: NR | hCG | 3 | 72 | 75
Lewis, Queenan, Hoeger, et al., 2006 #53610 | | | Definition(s) of outcome(s): Pregnancy: rising hCG and then viable when fetal pole with cardiac activity seen on US Live birth: NR Multiples: Yes Complications: NR | LH surge | 2 | 73 | 75
Lewis, Queenan, Hoeger, et al., 2006 #53610 | | | Definition(s) of outcome(s): Pregnancy: rising hCG and then viable when fetal pole with cardiac activity seen on US Live birth: NR Multiples: Yes Complications: NR | | 5 | 145 | 150
Lewis, Queenan, Hoeger, et al., 2006 #53610 | | | Definition(s) of outcome(s): Pregnancy: rising hCG and then viable when fetal pole with cardiac activity seen on US Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95% CI
Rel risk | 1.50 | 0.26 | 8.72
Malkawi and Qublan, 2002 #58360 | Geographical location: Amman, Jordan Study dates: Jan 2001–July 2001 Size of population (no. of patients): 28 Number of cycles analyzed: 168 Number of cycles per patient: 6 Study type: RCT Interventions: Metformin 850 mg BID or placebo, plus CC 50 mg days 5–9; CC dose increased in subsequent cycles if no response | Age: Mean (SD): NR, but stated no significant Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 28 (100%) Inclusion criteria:; - Presence of polycystic ovaries on vaginal ultrasound; - Examination combined with 3 or more of the following criteria: oligomenorrhea (< 6 menstrual periods in the preceding year); hirsutism (when Ferriman-Gallwey score >7); hyperandrogenemia (elevated free estosterone, androstenedione, dehydroepiandrosterone sulfate, [DHEAS]), and elevated concentrations [LH]); or LH: follicle stimulating hormone (FSH) ratio>2. Congenital adrenal hyperplasia, Cushing's syndrome, hyperprolactinemia and thyroid disease were excluded by appropriate tests. Clomiphene citrate resistance was defined as failure to ovulate or to conceive after CC treatment up to a daily dose of 150 mg from cycle day 5–9 for at least 3 consecutive cycles.; Exclusion criteria: Abnormal pelvic anatomy, abnormal semen analysis | Definition(s) of outcome(s): Pregnancy: gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Malkawi and Qublan, 2002 #58360 | | | Definition(s) of outcome(s): Pregnancy: gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Malkawi and Qublan, 2002 #58360 | | | Definition(s) of outcome(s): Pregnancy: gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | Metformin | 9 | 7 | 16 | Comments: None Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Malkawi and Qublan, 2002 #58360 | | | Definition(s) of outcome(s): Pregnancy: gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | Placebo | 2 | 10 | 12 | Comments: None Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Malkawi and Qublan, 2002 #58360 | | | Definition(s) of outcome(s): Pregnancy: gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | Total | 11 | 17 | 28 | Comments: None Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Malkawi and Qublan, 2002 #58360 | | | Definition(s) of outcome(s): Pregnancy: gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Malkawi and Qublan, 2002 #58360 | | | Definition(s) of outcome(s): Pregnancy: gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 3.38 | 0.89 | 12.85 | Comments: None Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Malkawi and Qublan, 2002 #58360 | | | Definition(s) of outcome(s): Pregnancy: gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | 2) OHSS: | | | | Comments: None Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Malkawi and Qublan, 2002 #58360 | | | Definition(s) of outcome(s): Pregnancy: gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | | OHSS + | OHSS - | Total | Comments: None Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Malkawi and Qublan, 2002 #58360 | | | Definition(s) of outcome(s): Pregnancy: gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | Metformin | 0 | 16 | 16 | Comments: None Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Malkawi and Qublan, 2002 #58360 | | | Definition(s) of outcome(s): Pregnancy: gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | Placebo | 2 | 10 | 12 | Comments: None Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Malkawi and Qublan, 2002 #58360 | | | Definition(s) of outcome(s): Pregnancy: gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | Total | 2 | 26 | 28 | Comments: None Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Malkawi and Qublan, 2002 #58360 | | | Definition(s) of outcome(s): Pregnancy: gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.15 | 0.01 | 2.92
Matorras, Recio, Corcostegui, et al., 2000 #7800 | Geographical location: Viscaya, Spain Study dates: Sep 1997–Sep 1998 Size of population: 91 Number of cycles analyzed: 345 Number of cycles per patient: 3.79 Study type: RCT Interventions: Compares rFSH and uFSH in IUI with husband's spermatozoa | Age: Range: 18–40 Race/ethnicity (n [%]): NR Diagnoses (%): Endometriosis:; - rFSH: 28.9; - uFSH: 34.7; Male factor:; - rFSH: 57.77; - uFSH: 58.69; Tubal factor:; - rFSH: 22.2; - uFSH: 20.0; Other (specify): Ovulation disorder:; - rFSH: 11.1; - uFSH: 13.6; Inclusion criteria:; - At least one normal tube; - Failure to obtain pregnancy in six cycles of programmed intercourse, under ovarian stimulation with gonadotropins; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy rate: | | | | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Matorras, Recio, Corcostegui, et al., 2000 #7800 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Matorras, Recio, Corcostegui, et al., 2000 #7800 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | uFSH | 24 | 22 | 46 | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Matorras, Recio, Corcostegui, et al., 2000 #7800 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | rFSH | 25 | 20 | 45 | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Matorras, Recio, Corcostegui, et al., 2000 #7800 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 49 | 42 | 91 | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Matorras, Recio, Corcostegui, et al., 2000 #7800 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Matorras, Recio, Corcostegui, et al., 2000 #7800 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.94 | 0.64 | 1.37 | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Matorras, Recio, Corcostegui, et al., 2000 #7800 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 2) Pregnancy rate: | | | | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Matorras, Recio, Corcostegui, et al., 2000 #7800 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | rFSH | uFSH | | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Matorras, Recio, Corcostegui, et al., 2000 #7800 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Per woman (%) | 45 | 46 | | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Matorras, Recio, Corcostegui, et al., 2000 #7800 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Per intention-to-treat PR | 57.8 (26/45) | 52.2 (24/46) | | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Matorras, Recio, Corcostegui, et al., 2000 #7800 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Corrected PR | 56.8 (25/44) | 52.2 (24/46) | | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Matorras, Recio, Corcostegui, et al., 2000 #7800 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Cumulative PR | 69.9 | 61 | | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Matorras, Recio, Corcostegui, et al., 2000 #7800 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | No statistically significant differences between the 2 grps. | | | | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Matorras, Recio, Corcostegui, et al., 2000 #7800 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 3) Cancellation rate: | 14.7% | 14.8% | | Comment: Cumulative pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
No statistically significant difference between the 2 grps.
Moll, Bossuyt, Korevaar, et al., 2006 #60030 | Geographical location: Netherlands (20 sites) Study dates: June 2001–May 2003 Size of population (no. of patients): 225 Number of cycles analyzed: Up to 6 cycles per patient Number of cycles per patient: > 1.0 Study type: RCT Interventions: Randomized to metformin (1000 mg/day) + clomiphene (dose increased as needed) vs clomiphene + placebo | Age: Mean (SD): CC + metformin: 27.9 (3.7) CC only: 28.4 (4.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 225 (100%) Inclusion criteria:; - Chronic anovulation (menstrual cycle ≥ 35 days, WHO type II, normogonadotropic, normoestrogenic, oligoanovulation or anovulation); - Polycystic ovaries diagnosed by transvaginal ultrasonography; - Wanted to conceive; Exclusion criteria:; - Other causes of anovulation; - Age > 40 years; - Liver, kidney, or heart disease or failure; - Partner's sperm quality indicated male factor subfertility (total motile count < 10×10^6^) | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Ongoing pregnancy per randomized subject: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Moll, Bossuyt, Korevaar, et al., 2006 #60030 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Moll, Bossuyt, Korevaar, et al., 2006 #60030 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Metformin + CC | 44 | 67 | 111 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Moll, Bossuyt, Korevaar, et al., 2006 #60030 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | CC only | 51 | 63 | 114 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Moll, Bossuyt, Korevaar, et al., 2006 #60030 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 95 | 130 | 225 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Moll, Bossuyt, Korevaar, et al., 2006 #60030 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.89 | 0.65 | 1.20
Ng, Makkar, Yeung, et al., 2003 #15610 | Geographical location: Hong Kong Study dates: NR Size of population (no. of patients): 90 Number of cycles analyzed: 204 Number of cycles per patient: 2.3 cycles/patient Study type: RCT Interventions: Population: Patients undergoing ovarian stimulation Compare single IUI (SIUI) to double IUI (DIUI) to fallopian tube sperm perfusion (FSP) SIUI: 38 hrs after hCG FSP: 38 hrs after hCG DIUI: 18 and 42 hrs after hCG | Age: Mean (SD): SIUI: 32.7± 2.4 DIUI: 32.9 ± 2.7 FSP: 32.9 ± 3.1 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 19 (21%) Endometriosis: 37 (41%) Male factor: 34 (38%) Inclusion criteria:; - Age < 40; - Infertility > 2 years; - Regular ovulatory cycles based on midluteal progesterone nmol/L; - Bilateral tubal patency and absence of peritubal adhesions by laparoscopy with chromotubation; - Total motile speramatozoa ≥ 10million; Exclusion criteria:; - Previous artificial insemination cycles; - Total motile sperm < 10 million | Definition(s) of outcome(s): Pregnancy: + hCG and US to confirm intrauterine pregnancy or products of conception on histology for miscarriages; ongoing if beyond 10–12 weeks Live birth: US to confirm number of gestational sacs Multiples: US to confirm number of gestational sacs Complications: NR | 1) Ongoing pregnancy : | | | | Comments:; - DIUI regimen is different which affects blinding; - No allocation concealment; Quality assessment: Randomization method: + Blinding: -, DIUI different regimen Dropout rate < 20%: + Adequacy of randomization concealment: -, not discussed
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | - Compare FSP vs SIUI
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | | Preg + | Preg -
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | FSP | 15 | 15 | 30
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | SIUI | 7 | 23 | 30
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | | 22 | 38 | 60
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | | | Lower 95% CI | Upper 95 % CI
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | Rel risk | 2.14 | 1.02 | 4.49
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | - Compare DIUI vs FSP
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | | Preg + | Preg -
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | FSP | 15 | 15 | 30
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | DIUI | 5 | 25 | 30
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | | 20 | 40 | 60
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | | | Lower 95% CI | Upper 95 % CI
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | Rel risk | 3.00 | 1.25 | 7.21
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | - Compare DIUI vs SIUI
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | | Preg + | Preg -
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | DIUI | 5 | 25 | 30
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | SIUI | 7 | 23 | 30
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | | 12 | 48 | 60
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | | | Lower 95% CI | Upper 95 % CI
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | Rel risk | 0.71 | 0.25 | 2.00
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | 2) Multiple gestations: no difference
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | SIUI: 2/30 (6.6%)
Ng, Makkar, Yeung, et al., 2003 #15610 | | | | DIUI: 1/30 (3.3%)
FSP: 5/30 (16.6%)
Ng, Wat, and Ho, 2001 #58450 | Geographical location: Hong Kong, China Study dates: Jan 1999–Dec 1999 Size of population (no. of patients): 20 Number of cycles analyzed: 20 Number of cycles per patient: 1.0 Study type: RCT Interventions: Metformin 500 mg TID or placebo × 3 cycles, with CC added if no ovulation after 3 cycles | Age: Mean (SD): Median: Range: Race/ethnicity (n [%]): Asian: 20 (100%) Diagnoses (n [%]): PCOS: 20 (100%) Inclusion criteria:; - Age < 40; - PCOS with no response to 100 mg CC over 3 cycles; - Normal tubes, uterus; Exclusion criteria:; - Smoking; - Renal impairment; - Use of sex steroids past 3 months | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Wat, and Ho, 2001 #58450 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Out + | Out - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Wat, and Ho, 2001 #58450 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Metformin | 1 | 9 | 10 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Wat, and Ho, 2001 #58450 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Placebo | 2 | 8 | 10 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Wat, and Ho, 2001 #58450 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 3 | 17 | 20 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Wat, and Ho, 2001 #58450 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.50 | 0.05 | 4.67
Ortega-Gonzalez, Luna, Hernandez, et al., 2005 #10460 | Geographical location: Mexico City, Mexico Study dates: NR Size of population (no. of patients): 52 Number of cycles analyzed: NR, but treated for 6 months Number of cycles per patient: [please calculate] >1.0 Study type: RCT Interventions: Population: Women with PCOS Group 1: pioglitazone (30mg/d)for 24 wks Group 2: metformin (850mg tid) for 24 wks | Age: Mean (SD): Pioglitazone: 28.8 ± 0.9 Metformin: 29.0 ± 0.8 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: Endometriosis: Male factor: Tubal factor: PCOS: 52 (100%) Other (specify): Inclusion criteria:; - PCOS defined as at least 2 of 3 of the following:; i) oligomenorrhea or amenorrhea; ii) serum androstenedione > 2.9ng/ml; iii) serum testosterone > 2.5pg/ml; iv) polycystic ovaries by US; Exclusion criteria:; - Impaired glucose tolerance test or Type II diabetes mellitus; - Hyperprolactinemia; - Thyroid disorders; - Late-onset CAH; - Cushing's syndrome; - No CC, OCPs, antiandrogens or medications for appetite control during previous 6 months | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: Metformin: 4 women discontinued therapy secondary to severe gastrointestinal side effects | 1) Pregnancy (intention to treat) | | | | Comments:; - Not blinded because pioglitazone was daily dosing vs metformin was tid; - No intention to treat analysis. In fact, one criterion for exclusion was loss to follow-up.; - Overall dropout was 9/52 = 17% but dropout for metformin group was 6/27 = 22%.; Quality assessment: Randomization method: + Blinding: - because daily vs tid dosing for Group 1 vs 2 Dropout rate < 20%: + Adequacy of randomization concealment: +
Ortega-Gonzalez, Luna, Hernandez, et al., 2005 #10460 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: Metformin: 4 women discontinued therapy secondary to severe gastrointestinal side effects | | Preg + | Preg -
Ortega-Gonzalez, Luna, Hernandez, et al., 2005 #10460 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: Metformin: 4 women discontinued therapy secondary to severe gastrointestinal side effects | Pioglitazone | 5 | 20 | 25
Ortega-Gonzalez, Luna, Hernandez, et al., 2005 #10460 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: Metformin: 4 women discontinued therapy secondary to severe gastrointestinal side effects | Metformin | 3 | 24 | 27
Ortega-Gonzalez, Luna, Hernandez, et al., 2005 #10460 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: Metformin: 4 women discontinued therapy secondary to severe gastrointestinal side effects | | 8 | 44 | 52
Ortega-Gonzalez, Luna, Hernandez, et al., 2005 #10460 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: Metformin: 4 women discontinued therapy secondary to severe gastrointestinal side effects | | | Lower 95% CI | Upper 95 % CI
Ortega-Gonzalez, Luna, Hernandez, et al., 2005 #10460 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: Metformin: 4 women discontinued therapy secondary to severe gastrointestinal side effects | Rel risk | 1.80 | 0.48 | 6.76
Ortega-Gonzalez, Luna, Hernandez, et al., 2005 #10460 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: Metformin: 4 women discontinued therapy secondary to severe gastrointestinal side effects | 2) Live birth (intention to treat)
Ortega-Gonzalez, Luna, Hernandez, et al., 2005 #10460 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: Metformin: 4 women discontinued therapy secondary to severe gastrointestinal side effects | | Live birth + | Live birth -
Ortega-Gonzalez, Luna, Hernandez, et al., 2005 #10460 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: Metformin: 4 women discontinued therapy secondary to severe gastrointestinal side effects | | 2 | 23 | 25
Ortega-Gonzalez, Luna, Hernandez, et al., 2005 #10460 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: Metformin: 4 women discontinued therapy secondary to severe gastrointestinal side effects | Pioglitazone | 2 | 25 | 27
Ortega-Gonzalez, Luna, Hernandez, et al., 2005 #10460 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: Metformin: 4 women discontinued therapy secondary to severe gastrointestinal side effects | Metformin | 4 | 48 | 52
Ortega-Gonzalez, Luna, Hernandez, et al., 2005 #10460 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: Metformin: 4 women discontinued therapy secondary to severe gastrointestinal side effects | | | Lower 95 % CI | Upper 95 % CI
Rel risk | 1.08 | 0.16 | 7.10
Palomba, Falbo, Orio, et al., 2005 #39590 | Geographical location: Naples, Italy Study dates: May 2002–June 2003 Size of population: 70 Number of cycles analyzed: 172 Number of cycles per patient: 2.45 Study type: RCT Interventions: Randomized controlled trial evaluating metformin pretreatment and co-administration in non-obese insulin-resistant women with PCOS who undergoing COH plus timed intercourse or IUI. Each pt received Metformin or placebo for 12 prior to start COH cycle using low dose gonadotropins. | Age: Mean (SD): Metformin 26.2 (2.7) Control 26.9 (2.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100% Inclusion criteria:; - PCOS diagnosed using NIH criteria; - Failed CC treatment; Exclusion criteria:; - Age < 20 or > 34; - BMI < 18 or > 30; - Medical conditions (neoplastic, metabolic exclude glucose intolerance, hepatic, cardiovascular, hypothyroidism, CAH, Cushing's syndrome, abuse of alcohol, current; - Use of OCP, glucocorticoids, antiandrogens, antidiabetic, anti-obesity and other hormone drugs; - Organic pelvic diseases Previous pelvic surgery,; - Suspected peritoneal factor infertility,; - Tubal infertility; - Male factor infertility; - Intended to start a diet or a specific program of physical activity | Definition(s) of outcome(s): Pregnancy: US showed evidence of intrauterine gestational sac Live birth: Percentage of women with baby alive/women who achieve a pregnancy Multiples: Yes Abortion: Percentage of early pregnancy losses (within the first 12 wk of gestation)/total pregnancies Complications: OHSS | 1) Pregnancy rate: | | | | Comment:; - Underpowered for primary outcome of multiple pregnancy rate; - Cumulative pregnancy rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | | Preg + | Preg -
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Metform | 18 | 17 | 35
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Placebo | 14 | 21 | 35
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | | 32 | 38 | 70
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | | | Lower 95% CI | Upper 95 % CI
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Rel risk | 1.29 | 0.77 | 2.16
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | 2) Abortion rate:
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | | Abort + | Abort - | Total
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Met | 1 | 17 | 18
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Placebo | 2 | 12 | 14
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Total | 3 | 29 | 32
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | | Value | Lower 95% CI | Upper 95% CI
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Rel risk | 0.39 | 0.04 | 3.87
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | 3) Live birth rate:
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | | LB + | LB -
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Met | 17 | 18 | 35
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Placebo | 12 | 23 | 35
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | | 29 | 41 | 70
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | | | Lower 95% CI | Upper 95% CI
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Rel risk | 1.42 | 0.80 | 2.51
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | 4) OHHS:
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | | OHSS + | OHSS - | Total
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Met | 0 | 85 | 85
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Placebo | 1 | 86 | 87
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Total | 1.5 | 171 | 172.5
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | | Value | Lower 95% CI | Upper 95% CI
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Rel risk | 0.51 | 0.02 | 14.97
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | 5) Multiple pregnancy rate:
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | | Multi preg + | Multi preg - | Total
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Met | 2 | 16 | 18
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Placebo | 5 | 9 | 14
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | Total | 7 | 25 | 32
Palomba, Falbo, Orio, et al., 2005 #39590 | | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.31 | 0.07 | 1.37
Palomba, Orio, Balbo, et al., 2005 #60060 | Geographical location: Catanzaro, Italy Study dates: Apr 2003–Sep 2003 Size of population (no. of patients): 100 Number of cycles analyzed: Up to 6 per patient Number of cycles per patient: > 1.0 Study type: RCT Interventions: Metformin 850 mg/day + placebo for 5 days, or clomiphene 150 mg/day for 5 days + placebo | Age: Mean (SD): Metformin: 26.4 (2.9) Clomiphene: 25.9 (2.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100% Inclusion criteria: PCOS by WHO criteria Exclusion criteria:; - Age < 20 or > 34; - BMI > 30 kg/m^2^; - Neoplastic, metabolic (including glucose intolerance), hepatic, and cardiovascular disorders or other concurrent medical illnesses; - Hypothyroidism, hyperprolactinemia, Cushing's syndrome, or nonclassical congenital adrenal hyperplasia; - Current or previous (within the last 6 months) use of oral contraceptives, glucocorticoids, antiandrogens, ovulation induction agents, antidiabetic and antiobesity drugs, or other hormonal drugs; - No uterine bleeding after progesterone challenge test; - Organic pelvic diseases; - Previous pelvic surgery; - Suspected peritoneal factor infertility; - Tubal or male factor infertility; - Planning a diet | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | 1) Pregnancy per randomized subject: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Balbo, et al., 2005 #60060 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Balbo, et al., 2005 #60060 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Metformin | 31 | 19 | 50 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Balbo, et al., 2005 #60060 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | CC | 16 | 34 | 50 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Balbo, et al., 2005 #60060 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Total | 47 | 53 | 100 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Balbo, et al., 2005 #60060 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Balbo, et al., 2005 #60060 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.94 | 1.22 | 3.06 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Balbo, et al., 2005 #60060 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | 2) Live birth per randomized subject: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Balbo, et al., 2005 #60060 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Balbo, et al., 2005 #60060 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Metformin | 26 | 24 | 50 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Balbo, et al., 2005 #60060 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | CC | 9 | 41 | 50 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Balbo, et al., 2005 #60060 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Total | 35 | 65 | 100 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Balbo, et al., 2005 #60060 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 2.89 | 1.51 | 5.53
Palomba, Orio, Falbo, et al., 2005 #39110 | Geographical location: Naples, Italy Study dates: NR (article did state that the investigators followed pts for 6 mo) Size of population: 28 Number of cycles analyzed: 110 Number of cycles per patient: 3.9 Study type: RCT Interventions: Pts with CC-resistant PCOS were previously randomized to Metformin + diagnostic laparoscopy vs. Laparoscopic ovarian drilling+placebe. Pts who had not ovulated after 6 mo of the treatments were then enrolled in this study. Everyone received Clomid 150 mg × 5 d from D3–7 each month. Ovulation, pregnancy, abortion rate, and live-birth rates were evaluated in each grp | Age: Mean (SD): Metformin: 27.2 (2.2) Ovarian drilling: 25.4 (2.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 0 Endometriosis: 0 Male factor: 0 Tubal factor: 0 PCOS: 0 Other (specify): 0 Inclusion criteria:; - Anovulation after 6 mo of; - Metformin or ovarian drilling; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Appropriate increase of hCG and +gestational sac on US Live birth: Percentage of women with baby alive/women who achieve a pregnancy Multiples: NR Complications: Abortion rate; percentage of miscarriage during the first 12 wk of gestation/total pregnancy | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | | Out + | Out - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | Metform | 6 | 2 | 8 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | Ovarian drilling | 12 | 8 | 20 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | Total | 18 | 10 | 28 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | Rel risk | 1.25 | 0.73 | 2.14 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | 2) Live birth rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | | Out + | Out - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | Metform | 4 | 4 | 8 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | Ovarian drilling | 7 | 13 | 20 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | Total | 11 | 17 | 28 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | Rel risk | 1.43 | 0.57 | 3.57 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | 3) Abortion rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | | Out + | Out - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | Metform | 2 | 4 | 6 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | Ovarian drilling | 5 | 7 | 12 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | Total | 7 | 11 | 18 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Palomba, Orio, Falbo, et al., 2005 #39110 | | | | Rel risk | 0.80 | 0.21 | 2.98 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
4) No difference in ovulation rate between 2 groups
Palomba, Orio, Nardo, et al., 2004 #12340 | Geographical location: Catanzaro, Italy Study dates: Oct 2001–Dec 2002 Size of population (no. of patients): 120 Number of cycles analyzed: 441 Number of cycles per patient: 120/441 = 0.27 Study type: RCT Interventions: Population: overweight CC-resistant women with PCOS Comparison of laparoscopic ovarian diathermy (LOD) + metformin vs LOD only Group A: Diagnostic laparoscopy f/b 6 months metformin cloridrate (850 mg bid) Group B: Laparoscopic ovarian diathermy f/b 6 months of multivitamins | Age: Mean (SD): LOD + metformin: 26.8 ± 2.2 LOD: 27.5 ± 2.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 120 (100%) But PCOS with glucose intolerance was excluded Inclusion criteria:; - PCOS defined by NIH criteria; - CC resistance defined as failure to ovulate during ≥ 3 consecutive cycles using CC 150 mg qd from d3–7.; - Overweight defined as BMI 25–30 kg/m^2^; Exclusion criteria:; - Age < 22 or > 34; - PCOS with glucose intolerance; - Hypothyroidism; - Hyperprolactinemia; - Cushing's syndrome; - Nonclassical CAH; - Use of the following within the last 6 mos: OCPs, Glucocorticoids, Antiandrogens, Ovulation induction agents, Antidiabetic or Antiobesity medications, Other hormonal drugs; - Neoplastic, metabolic, hepatic, cardiovascular disorders or other concurrent medical illness (i.e. diabetes, renal disease or malabsorptive disorders).; - Diet or physical activity program; - Organic pelvic disease, previous pelvic surgery, suspected peritoneal factor infertility and tubal or male factor infertility; - Smoking or drinking alcoholic beverages | Definition(s) of outcome(s): Pregnancy: rising β-hcg and intrauterine gestational sac on US Live birth: Baby alive Multiples: NR Complications: Drug-related adverse event = diarrhea, flatulence and nausea; abortion rate | 1) Pregnancy (intention-to-treat): | | | | Comments:; - No intention-to-treat analysis; - Metformin and multivitamin may have different appearance; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + (9%) Adequacy of randomization concealment: +
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | | Preg + | Preg -
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | LOD + metformin | 39 | 21 | 60
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | LOD + placebo | 31 | 29 | 60
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | | 70 | 50 | 120
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | | | Lower 95% CI | Upper 95 % CI
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | Rel risk | 1.26 | 0.93 | 1.71
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | 2) Live birth (intention-to-treat):
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | | Live birth+ | Live birth-
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | LOD + metformin | 32 | 28 | 60
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | LOD + placebo | 20 | 40 | 60
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | | 52 | 68 | 120
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | | | Lower 95% CI | Upper 95 % CI
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | Rel risk | 1.60 | 1.04 | 2.46
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | 3) Abortion rate (no. abortions / no. pregnancies):
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | LOD + metformin: 15.4%
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | LOD + placebo: 29.0%
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | 4) Drug-related adverse events:
Palomba, Orio, Nardo, et al., 2004 #12340 | | | | LOD + metformin: 22.2%
LOD + placebo: 5.5%
Perez-Medina, Bajo-Arenas, Salazar, et al., 2005 #41940 | Geographical location: Madrid, Spain Study dates: Jan 2000 – Feb 2004 Size of population (no. of patients): 215 Number of cycles analyzed: NR but multiple cycles per patient Number of cycles per patient: unable to calculate because total number of cycles NR Study type: RCT Interventions: Population: Infertile women with endometrial polyps diagnosed on US undergoing IUI Compare hysteroscopic polypectomy with scissors and forceps to diagnostic hysteroscopy and polyp biopsy (no additional details on how biopsy was performed) | Age: Mean (SD): Polypectomy 30.8 ± 4.1 Biopsy: 30.9 ± 4.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]):; - Some cases have multiple factors; Unexplained infertility: 105 (49%) Endometriosis: 23(11%) Male factor: 46 (21%) Tubal factor: 0 PCOS: Other (specify): Ovulatory 71 (33%) Cervical 24 (11%); - No difference in mean size (16mm) of polyps between groups; Inclusion criteria:; - Infertility > 24 months; - US diagnosis of endometrial polyp; - Candidate for IUI; Exclusion criteria:; - Age > 39; - Anovulation; - Azoospermia; - Uncorrected tubal disease; - Previous unsuccessful use of rFSH | Definition(s) of outcome(s): Pregnancy: + hCG followed by TVUS 2 weeks later Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy (intention to treat): | | | | Comments:; - No intention to treat analysis; - No information about blinding; Quality assessment: Randomization method: + Blinding: -, not discussed Dropout rate < 20%: +, 5% (11/215) Adequacy of randomization concealment: +
Perez-Medina, Bajo-Arenas, Salazar, et al., 2005 #41940 | | | Definition(s) of outcome(s): Pregnancy: + hCG followed by TVUS 2 weeks later Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Perez-Medina, Bajo-Arenas, Salazar, et al., 2005 #41940 | | | Definition(s) of outcome(s): Pregnancy: + hCG followed by TVUS 2 weeks later Live birth: NR Multiples: NR Complications: NR | Polypectomy | 64 | 43 | 107
Perez-Medina, Bajo-Arenas, Salazar, et al., 2005 #41940 | | | Definition(s) of outcome(s): Pregnancy: + hCG followed by TVUS 2 weeks later Live birth: NR Multiples: NR Complications: NR | Biopsy | 29 | 79 | 108
Perez-Medina, Bajo-Arenas, Salazar, et al., 2005 #41940 | | | Definition(s) of outcome(s): Pregnancy: + hCG followed by TVUS 2 weeks later Live birth: NR Multiples: NR Complications: NR | | 93 | 122 | 215
Perez-Medina, Bajo-Arenas, Salazar, et al., 2005 #41940 | | | Definition(s) of outcome(s): Pregnancy: + hCG followed by TVUS 2 weeks later Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 2.23 | 1.57 | 3.15
Revelli, Poso, Gennarelli, et al., 2006 #55220 | Geographical location: Torino, Italy Study dates: NR Size of population (no. of patients): 260 Number of cycles analyzed: 260 Number of cycles per patient: 1 Study type: RCT Interventions: Low-dose step up regimen Randomized to highly purified urinary FSH vs. recombinant FSH Ovulation triggered with hCG, timed intercourse Ovulation only triggered if 1 follicle | Age: Mean (SD): 32.7 (4.3) Range: 28–38 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 184 (70.8%) PCOS: 76 (29.2%) This table only includes data for PCOS patients, all clomiphene-resistant Inclusion criteria:; - > 1 year infertility; - Good general health; - Normal tubes/uterus; - Normal semen analysis; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac at 7 weeks Live birth: Yes Multiples: NR Complications: NR | 1) Live birth: | | | | Comments:; - This table only includes data for PCOS patients, all clomiphene-resistant; - Subgroup analysis of combined study of both unexplained infertility and PCOS; overall RR for uFSH vs. rFSH 0.76 (95% CI 0.39, 1.51); Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Revelli, Poso, Gennarelli, et al., 2006 #55220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Revelli, Poso, Gennarelli, et al., 2006 #55220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 7 weeks Live birth: Yes Multiples: NR Complications: NR | HP-uFSH | 4 | 35 | 39
Revelli, Poso, Gennarelli, et al., 2006 #55220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 7 weeks Live birth: Yes Multiples: NR Complications: NR | rFSH | 7 | 30 | 35
Revelli, Poso, Gennarelli, et al., 2006 #55220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | 11 | 65 | 74
Revelli, Poso, Gennarelli, et al., 2006 #55220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Revelli, Poso, Gennarelli, et al., 2006 #55220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 7 weeks Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.51 | 0.16 | 1.63
2) Lower number of vials of rFSH used; lower overall costs in cost minimization analysis
Rizk, Bedaiwy, and Al-Inany, 2005 #10620 | Geographical location: Cairo, Egypt Study dates: Mar 2002–Nov 2003 Size of population (no. of patients): 150 Number of cycles analyzed: 150 Number of cycles per patient: 1 Study type: RCT Interventions: Population: CC-resistant PCOS women Compare N-acetyl-cysteine (NAC) vs. placebo Group 1: NAC 1.2 g/d with CC 100 mg/d days 3–7 Group 2: placebo (sugar) with CC 100 mg/d days 3–7 | Age: Mean (SD): Group 1: 28.9 ± 4.7 Group 2: 28.4 ± 5.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 150 (100%) Inclusion criteria:; - PCOS definition: bilaterally normal or enlarged ovaries with at least 7–10 peripheral cysts; - CC resistance defined as lack of ovulation after CC 100 mg for 5 days in 3 consecutive cycles; - Ages 18–29; - 1 patent fallopian tube by HSG or laparoscopy; - Normal semen analysis; Exclusion criteria:; - Hyperprolactinemia; - Clinical evidence of hypercorticism; - Thyroid dysfunction; - Hormonal medication except for progesterone 2 months prior | Definition(s) of outcome(s): Pregnancy: Viable pregnancy at least 12 weeks after hCG administration Live birth: NR Multiples: Yes Complications: OHSS | 1) Pregnancy: | | | | Comments: With sugar as the placebo, questionable blinding if there is a different taste between NAC and sugar Quality assessment: Randomization method: + Blinding: + (physicians blinded but patients may not be because placebo [sugar] may have a different taste than NAC) Dropout rate < 20%: + Adequacy of randomization concealment: +
Rizk, Bedaiwy, and Al-Inany, 2005 #10620 | | | Definition(s) of outcome(s): Pregnancy: Viable pregnancy at least 12 weeks after hCG administration Live birth: NR Multiples: Yes Complications: OHSS | | Preg + | Preg -
Rizk, Bedaiwy, and Al-Inany, 2005 #10620 | | | Definition(s) of outcome(s): Pregnancy: Viable pregnancy at least 12 weeks after hCG administration Live birth: NR Multiples: Yes Complications: OHSS | NAC | 14 | 61 | 75
Rizk, Bedaiwy, and Al-Inany, 2005 #10620 | | | Definition(s) of outcome(s): Pregnancy: Viable pregnancy at least 12 weeks after hCG administration Live birth: NR Multiples: Yes Complications: OHSS | placebo | 0 | 75 | 75
Rizk, Bedaiwy, and Al-Inany, 2005 #10620 | | | Definition(s) of outcome(s): Pregnancy: Viable pregnancy at least 12 weeks after hCG administration Live birth: NR Multiples: Yes Complications: OHSS | | 14.49 | 136 | 150
Rizk, Bedaiwy, and Al-Inany, 2005 #10620 | | | Definition(s) of outcome(s): Pregnancy: Viable pregnancy at least 12 weeks after hCG administration Live birth: NR Multiples: Yes Complications: OHSS | | | Lower 95% CI | Upper 95 % CI
Rizk, Bedaiwy, and Al-Inany, 2005 #10620 | | | Definition(s) of outcome(s): Pregnancy: Viable pregnancy at least 12 weeks after hCG administration Live birth: NR Multiples: Yes Complications: OHSS | Rel risk | 28.76 | 1.70 | 487.61
Rizk, Bedaiwy, and Al-Inany, 2005 #10620 | | | Definition(s) of outcome(s): Pregnancy: Viable pregnancy at least 12 weeks after hCG administration Live birth: NR Multiples: Yes Complications: OHSS | 2) Multiple gestation:
Rizk, Bedaiwy, and Al-Inany, 2005 #10620 | | | Definition(s) of outcome(s): Pregnancy: Viable pregnancy at least 12 weeks after hCG administration Live birth: NR Multiples: Yes Complications: OHSS | | Multi + | Multi -
Rizk, Bedaiwy, and Al-Inany, 2005 #10620 | | | Definition(s) of outcome(s): Pregnancy: Viable pregnancy at least 12 weeks after hCG administration Live birth: NR Multiples: Yes Complications: OHSS | NAC | 5 | 70 | 75
Rizk, Bedaiwy, and Al-Inany, 2005 #10620 | | | Definition(s) of outcome(s): Pregnancy: Viable pregnancy at least 12 weeks after hCG administration Live birth: NR Multiples: Yes Complications: OHSS | placebo | 0 | 75 | 75
Rizk, Bedaiwy, and Al-Inany, 2005 #10620 | | | Definition(s) of outcome(s): Pregnancy: Viable pregnancy at least 12 weeks after hCG administration Live birth: NR Multiples: Yes Complications: OHSS | | 5.49 | 145 | 150
Rizk, Bedaiwy, and Al-Inany, 2005 #10620 | | | Definition(s) of outcome(s): Pregnancy: Viable pregnancy at least 12 weeks after hCG administration Live birth: NR Multiples: Yes Complications: OHSS | | | Lower 95% CI | Upper 95 % CI
Rizk, Bedaiwy, and Al-Inany, 2005 #10620 | | | Definition(s) of outcome(s): Pregnancy: Viable pregnancy at least 12 weeks after hCG administration Live birth: NR Multiples: Yes Complications: OHSS | Rel risk | 10.27 | 0.56 | 189.78
3) No cases of OHSS
Roudebush, Toledo, Kort, et al., 2004 #12880 | Geographical location: Atlanta, Georgia Study dates: Jan 2001 – Dec 2002 Size of population (no. of patients): 165 Number of cycles analyzed: 346 Number of cycles per patient: 2.1 Study type: RCT Interventions: Population: Patients with infertility underoing IUI. Cycle stimulation with CC or gonadotropins. If CC, 50–150mg CC for 5 days. IUI based on LH surge or US timed hCG administration. If gonadotropins, stimulations started on day 3 with 75–225 IU daily. IUI 12–18 hrs and then 36–38 hrs after hCG. Compare use of platelet activating factor (PAF) vs no PAF in control groups PAF treatment at the time of semen washing right before IUI For analysis, groups also divided by normal vs male factor study arm; also CC vs gonadotropin | Age: Mean (SD): Normal study arm:; 1 Control 36.2 ± 4.2; 2 PAF: 35.9 ± 4.9; Male factor arm:; 1 Control: 35.8 ±4.5; 2 PAF: 34.1 ± 4.4; Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 8 (5.5%) Endometriosis: 12 (8.3%) Male factor: 84 (57.9%) Tubal factor: 2 (1.4%) PCOS: Other (specify): Anovulatory: 35 (24.1%) Inclusion criteria:; - Healthy, infertile patients with nontubal factor infertility; - Infertility diagnoses included anovulatory, endometriosis, idiopathic, tubal (single or fibroids), cervical factor and male factor; - Male factor if failed to meet 1 or more reference standards; - Basal FSH < 15mIU/mL; - Normal uterine cavity; - No contraindication to pregnancy; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | 1) Pregnancy: | | | | Comments:; - No intention to treat analysis; - Cycle stimulation was done with either CC or gonadotropins and outcome could be affected by stimulation method and not necessarily PAF. Thus results presented as overall, CC stimulation only and gonadotropin only.; - No allocation concealment; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: - , not discussed
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | - Overall (both CC and gonadotropin stimulation), PAF vs control
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg -
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | PAF | 28 | 36 | 64
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | Control | 22 | 59 | 81
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | | 50 | 95 | 145
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | Rel risk | 1.61 | 1.02 | 2.53
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | - Only CC simulation, PAF vs control
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg -
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | PAF | 8 | 14 | 22
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | Control | 11 | 20 | 31
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | | 19 | 34 | 53
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | Rel risk | 1.02 | 0.49 | 2.12
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | - Only gonadotropin simulation, PAF vs control
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg -
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | PAF | 17 | 23 | 40
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | Control | 11 | 39 | 50
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | | 28 | 62 | 90
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | Rel risk | 1.93 | 1.02 | 3.64
Roudebush, Toledo, Kort, et al., 2004 #12880 | | | Definition(s) of outcome(s): Pregnancy: + hCG and fetal heartbeat on US Live birth: NR Multiples: Yes Complications: NR | 3) Multiple gestations: no difference
- Control 7/22 (31.8%); - PAF 7/28 (25.0%)
Rouzi and Ardawi, 2006 #55350 | Geographical location: Jeddah, Saudi Arabia Study dates: April 2002 – April 2004 Size of population (no. of patients): 25 Number of cycles analyzed: >1; - more than 1 cycle per patient but total number of cycles analyzed was not recorded; Number of cycles per patient: Unable to calculate given cycle numbers NR Study type: RCT Interventions: Population: CC-resistant PCOS. Rosiglitazone and CC:; - Rosiglitazone 4mg bid; - CC 100mg × 5 days starting on day 3; Metformin and CC:; - Metformin 500mg tid; - CC 100mg × 5 days starting on day 3 | Age: Rosiglitazone: Mean: 28.6±3.7 Range: 23–36 Metformin: Mean: 27.4±4.3 Range: 23–35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 25 (100%) Inclusion criteria:; - Ages 20–40; - Primary infertility & PCOS; - PCOS diagnosis based on the following:; 1 Oligomenorrhea (interval ≥ 35 days) or amenorrhea (absence of menses × 6 mos); 2 Hirsutism; 3 Enlarged ovaries with multiple follicles (> 10 measuring 2–8mm) arranged peripherally on TVUS; 4 Elevated serum testosterone; - Failure to ovulate with CC 150mg/d for 5 days starting on day 3; - Patent tubs by HSG; - No other infertility factor; Exclusion criteria:; - Adrenal dysfunction; - Cushing's syndrome; - CAH; - Androgen producing tumor; - Hyperprolactinemia; - Thyroid dysfunction; - Diabetes; - Taking medication that could influence carbohydrate metabolism; - Hypertension; - Prior use of gonadotropins; - H/o ovarian drilling; - Prior IVG; - Abnormal renal or liver function tests | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | 1) Pregnancy: | | | | Comments:; - Rosiglitazone dose was bid versus metformin dose was tid which affects blinding; - GI side effects associated with metformin may also affect blinding; Quality assessment: Randomization method:+ Blinding: -, dosing was different between the two groups Dropout rate < 20%: + Adequacy of randomization concealment: +
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | | Preg + | Preg -
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | Rosiglitazone | 6 | 6 | 12
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | Metformin | 5 | 8 | 13
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | | 11 | 14 | 25
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | | | Lower 95% CI | Upper 95 % CI
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | Rel risk | 1.30 | 0.53 | 3.17
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | 2) Live birth:
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | | Live birth + | Live birth -
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | Rosiglitazone | 5 | 7 | 12
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | Metformin | 4 | 9 | 13
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | | 9 | 16 | 25
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | | | Lower 95% CI | Upper 95 % CI
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | Rel risk | 1.35 | 0.47 | 3.89
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | 3) Multiple gestation:
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | | AE + | AE -
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | Rosiglitazone | 1 | 11 | 12
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | Metformin | 0 | 13 | 13
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | | 1.49 | 24 | 25
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | | | Lower 95% CI | Upper 95 % CI
Rouzi and Ardawi, 2006 #55350 | | | Definition(s) of outcome(s): Pregnancy: positive serum hcg followed by US Live birth: Yes Multiples: NR Complications: Drug-related adverse events: diarrhea, nausea and abdominal bloating | Rel risk | 2.29 | 0.08 | 63.98
4) Drug-related adverse events: Rosiglitzaone 0% vs Metformin 31% (4/13)
Sakhel, Khedr, Schwark, et al., 2007 #72400 | Geographical location: Saginaw, Rochester Hills, and Flint, MI Study dates: Apr 2003–Mar 2004 Size of population (no. of patients): 284 Number of cycles analyzed: 284 Number of cycles per patient: 1.0 Study type: RCT Interventions: GnRH antagonist with rFSH COH, randomized to (a) urinary hCG, or (b) recombinant hCG , followed by IUI | Age: Mean (SD): 32.3 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 22–44 years; - Non-tubal infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 4 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | 1) Clinical pregnancy: | | | | Comments: No IRB oversight Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sakhel, Khedr, Schwark, et al., 2007 #72400 | | Age: Mean (SD): 32.3 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 22–44 years; - Non-tubal infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 4 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | | Preg + | Preg - | Total | Comments: No IRB oversight Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sakhel, Khedr, Schwark, et al., 2007 #72400 | | Age: Mean (SD): 32.3 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 22–44 years; - Non-tubal infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 4 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | rhCG | 38 | 102 | 140 | Comments: No IRB oversight Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sakhel, Khedr, Schwark, et al., 2007 #72400 | | Age: Mean (SD): 32.3 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 22–44 years; - Non-tubal infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 4 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | uhCG | 41 | 103 | 144 | Comments: No IRB oversight Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sakhel, Khedr, Schwark, et al., 2007 #72400 | | Age: Mean (SD): 32.3 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 22–44 years; - Non-tubal infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 4 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | Total | 79 | 205 | 284 | Comments: No IRB oversight Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sakhel, Khedr, Schwark, et al., 2007 #72400 | | Age: Mean (SD): 32.3 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 22–44 years; - Non-tubal infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 4 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: No IRB oversight Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sakhel, Khedr, Schwark, et al., 2007 #72400 | | Age: Mean (SD): 32.3 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 22–44 years; - Non-tubal infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 4 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 0.95 | 0.66 | 1.39 | Comments: No IRB oversight Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sakhel, Khedr, Schwark, et al., 2007 #72400 | | Age: Mean (SD): 32.3 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 22–44 years; - Non-tubal infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 4 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | 2) Ongoing/live birth: | | | | Comments: No IRB oversight Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sakhel, Khedr, Schwark, et al., 2007 #72400 | | Age: Mean (SD): 32.3 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 22–44 years; - Non-tubal infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 4 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | | Out + | Out - | Total | Comments: No IRB oversight Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sakhel, Khedr, Schwark, et al., 2007 #72400 | | Age: Mean (SD): 32.3 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 22–44 years; - Non-tubal infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 4 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | rhCG | 31 | 109 | 140 | Comments: No IRB oversight Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sakhel, Khedr, Schwark, et al., 2007 #72400 | | Age: Mean (SD): 32.3 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 22–44 years; - Non-tubal infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 4 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | uhCG | 36 | 108 | 144 | Comments: No IRB oversight Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sakhel, Khedr, Schwark, et al., 2007 #72400 | | Age: Mean (SD): 32.3 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 22–44 years; - Non-tubal infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 4 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | Total | 67 | 217 | 284 | Comments: No IRB oversight Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sakhel, Khedr, Schwark, et al., 2007 #72400 | | Age: Mean (SD): 32.3 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 22–44 years; - Non-tubal infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 4 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: No IRB oversight Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sakhel, Khedr, Schwark, et al., 2007 #72400 | | Age: Mean (SD): 32.3 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 22–44 years; - Non-tubal infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 4 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 0.89 | 0.58 | 1.35 | Comments: No IRB oversight Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
3) Multiple rates similar
Sharma, Kriplani, and Agarwal, 2006 #58520 | Geographical location: New Delhi, India Study dates: NR Size of population (no. of patients): 20 Number of cycles analyzed: NR, but 6-month followup Number of cycles per patient: > 1.0 Study type: RCT Interventions: Unipolar or bipolar electrocautery of ovaries; no treatment for 3 months, CC if no ovulation | Age: Mean: Unipolar: 27.3 Bipolar: 25.5 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 20 (100%) Inclusion criteria:; - PCOS; - “Resistant” after 6 cycles of CC; - Patent tubes; - Normal semen analysis; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sharma, Kriplani, and Agarwal, 2006 #58520 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sharma, Kriplani, and Agarwal, 2006 #58520 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Bipolar | 7 | 3 | 10 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sharma, Kriplani, and Agarwal, 2006 #58520 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Unipolar | 5 | 5 | 10 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sharma, Kriplani, and Agarwal, 2006 #58520 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 12 | 8 | 20 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sharma, Kriplani, and Agarwal, 2006 #58520 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 1.40 | 0.67 | 2.94
Tartagni, Cicinelli, De Pergola, et al., 2007 #56100 | Geographical location: Bari, Italy Study dates: NR Size of population (no. of patients): 50 Number of cycles analyzed: NR; ?50 Number of cycles per patient: ?1.0 Study type: RCT Interventions: All scheduled for stimulation with rFSH; randomized to (a) 0.05 mg ethinyl estradiol TID for 2 weeks prior to stimulation vs. (b) placebo | Age: Mean (SD): E2 32.9 (3.9); placebo 32.5 (4.8) Range: 24–39 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Other: All with premature ovarian failure Inclusion criteria:; - Aamenorrhea ≥ 6 months; - Serum FSH ≥ 40 mIU/mL; - E2 ≤ 25 pg/mL at two separate measurements in the preceding 2 months; - Normal prolactin, chromosome; - No history of radiotherapy or chemotherapy; - Normal laboratory and physical; - No oral contraceptives or other hormone therapy within last 6 mo; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Tartagni, Cicinelli, De Pergola, et al., 2007 #56100 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Tartagni, Cicinelli, De Pergola, et al., 2007 #56100 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Estradiol | 12 | 13 | 25 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Tartagni, Cicinelli, De Pergola, et al., 2007 #56100 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Placebo | 0.5 | 25 | 25 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Tartagni, Cicinelli, De Pergola, et al., 2007 #56100 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 12.5 | 38 | 50 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Tartagni, Cicinelli, De Pergola, et al., 2007 #56100 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 24.00 | 1.50 | 384.61
Timmerman-van Kessel, Cikot, Dargel-Donkers, et al., 2000 #58590 | Geographical location: Eindhoven, the Netherlands Study dates: NR Size of population (no. of patients): 30 Number of cycles analyzed: 65 Number of cycles per patient: 2.1 Study type: RCT Interventions: PCOS, randomized to clomiphene days 3–7 vs. 3 weeks GnRH agonist suppression, followed by daily pulsatile IV GnRH | Age: Median (range): GnRH: 26 (22–31) CC: 27 (21–31) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 30 (100%) Inclusion criteria:; - Age < 40; - Primary infertility; - Oligo/amenorrhea; - LH > 6.5 and/or LH/FSH > 1.5; - Normal semen analysis; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy, intention to treat: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Timmerman-van Kessel, Cikot, Dargel-Donkers, et al., 2000 #58590 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Timmerman-van Kessel, Cikot, Dargel-Donkers, et al., 2000 #58590 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | GnRH | 4 | 12 | 16 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Timmerman-van Kessel, Cikot, Dargel-Donkers, et al., 2000 #58590 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | CC | 4 | 10 | 14 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Timmerman-van Kessel, Cikot, Dargel-Donkers, et al., 2000 #58590 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 8 | 22 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Timmerman-van Kessel, Cikot, Dargel-Donkers, et al., 2000 #58590 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Timmerman-van Kessel, Cikot, Dargel-Donkers, et al., 2000 #58590 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.88 | 0.27 | 2.86 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
2 CC patients did not receive treatment - per protocol RR 0.75
Tsai, Lin, Chen, et al., 2004 #12800 | Geographical location: Tainan, Taiwan Study dates: January 2002–Oct 2002 Size of population (no. of patients): 121 Number of cycles analyzed: 121 Number of cycles per patient: 1.0 Study type: RCT Interventions: Superovulation with clomiphene + rFSH, hCG trigger Fresh semen prepared by gradient separation, randomized to one of 2 media: Percoll vs PureSperm | Age: Mean (SD): Percoll 30.7 (3.8); PureSperm 31.6 (4.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 121 (100%) Inclusion criteria: Clomiphene resistance Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tsai, Lin, Chen, et al., 2004 #12800 | | Age: Mean (SD): Percoll 30.7 (3.8); PureSperm 31.6 (4.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 121 (100%) Inclusion criteria: Clomiphene resistance Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tsai, Lin, Chen, et al., 2004 #12800 | | Age: Mean (SD): Percoll 30.7 (3.8); PureSperm 31.6 (4.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 121 (100%) Inclusion criteria: Clomiphene resistance Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: NR Multiples: NR Complications: NR | PureSperm | 7 | 49 | 56 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tsai, Lin, Chen, et al., 2004 #12800 | | Age: Mean (SD): Percoll 30.7 (3.8); PureSperm 31.6 (4.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 121 (100%) Inclusion criteria: Clomiphene resistance Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: NR Multiples: NR Complications: NR | Percoll | 9 | 56 | 65 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tsai, Lin, Chen, et al., 2004 #12800 | | Age: Mean (SD): Percoll 30.7 (3.8); PureSperm 31.6 (4.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 121 (100%) Inclusion criteria: Clomiphene resistance Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: NR Multiples: NR Complications: NR | | 16 | 105 | 121 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tsai, Lin, Chen, et al., 2004 #12800 | | Age: Mean (SD): Percoll 30.7 (3.8); PureSperm 31.6 (4.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 121 (100%) Inclusion criteria: Clomiphene resistance Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.90 | 0.36 | 2.27
Unfer, Casini, Constabile, et al., 2004 #11280 | Geographical location: Rome, Italy Study dates: NR Size of population: Total: 134 CC + phytoestrogen (PE): 65 CC alone: 69 Number of cycles analyzed: 134 Number of cycles per patient: 1.00 Study type: RCT Interventions: Compares pregnancy rate in pts receiving CC + PE + IUI versus CC + IUI Also looks at endometrial thickness, uterine pulsatility index and SAB rate. | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 134 (100%) Inclusion criteria:; - Age 25–35; - 2 yr primary infertility; - Normal levels of TSH, prolactin and testosterone; Exclusion criteria:; - Previous infertility treatment; - Male factor or tubal factor infertility; - BMI > 25 | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | 1) Ongoing pregnancy rate: | | | | Comment:; - Low numbers; - Does not give age or weight of subjects in each grp, but does exclude BMI > 25; Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: - (NR) Adequacy of randomization concealment: +
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | | Ongoing preg + | Ongoing preg - | Total
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | CC + PE | 13 | 52 | 65
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | CC | 3 | 66 | 69
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | Total | 16 | 118 | 134
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | | Value | Lower 95% CI | Upper 95% CI
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | Rel risk | 4.60 | 1.37 | 15.41
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | 2) Biochemical pregnancy rate:
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | | Biochem preg + | Biochem preg - | Total
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | CC + PE | 3 | 62 | 65
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | CC | 4 | 65 | 69
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | Total | 7 | 127 | 134
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | | Value | Lower 95% CI | Upper 95% CI
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | Rel risk | 0.80 | 0.19 | 3.42
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | 3) SAB rate:
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | | SAB + | SAB - | Total
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | CC + PE | 2 | 63 | 65
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | CC | 6 | 63 | 69
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | Total | 8 | 126 | 134
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | | Value | Lower 95% CI | Upper 95% CI
Unfer, Casini, Constabile, et al., 2004 #11280 | | | Definition(s) of outcome(s): Pregnancy: Biochemical Ongoing > 20 wk EGA Live birth: NR Multiples: NR Complications: SAB | Rel risk | 0.35 | 0.07 | 1.69
4) No significant difference between groups in endometrial thickness or pulsatility index
Vandermolen, Ratts, Evans, et al., 2001 #58610 | Geographical location: Richmond and Charlottesville, VA; St. Louis, MO Study dates: NR Size of population (no. of patients): 27 Number of cycles analyzed: Up to 6 Number of cycles per patient: > 1 Study type: RCT Interventions: Metformin 500 mg TID vs. placebo × 7 weeks, followed by CC up to 6 cycles | Age: Mean (SD): Metformin 29 (± 1.2) Placebo 30 (± 1.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - 18–35 years of age; - Wanted to become pregnant; - Anovulatory in response to a 5-day course of CC, 150 mg/day (anovulation documented by failure to menstruate by cycle day 35 and a negative result on a pregnancy test or by a midluteal P level , 4 ng/mL); - Oligoovulation (< 6 menstrual periods annually); - Hyperandrogenism (by laboratory assay of androstenedione, free T, or total T or by clinical evidence of hirsutism); - Normal levels of TSH, PRL, and 17-hydroxyprogesterone (< 200 ng/dL) Normal renal function (serum creatinine concentration < 1.4 mg/dL); - Normal results on liver function tests; Exclusion criteria:; - Nonpatent tubes; - Abnormal semen analysis; - Diabetes | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Vandermolen, Ratts, Evans, et al., 2001 #58610 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Vandermolen, Ratts, Evans, et al., 2001 #58610 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Metformin + CC | 6 | 6 | 12 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Vandermolen, Ratts, Evans, et al., 2001 #58610 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Placebo + CC | 1 | 14 | 15 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Vandermolen, Ratts, Evans, et al., 2001 #58610 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Total | 7 | 20 | 27 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Vandermolen, Ratts, Evans, et al., 2001 #58610 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 7.50 | 1.04 | 54.12
Wu, Wang, Cheng, et al., 2007 #56740 | Geographical location: Changhua, Taiwan Study dates: June – November 2004 Size of population (no. of patients): 33 Number of cycles analyzed: NR Number of cycles per patient: NR Study type: RCT Interventions: Anastrozole (AI) 1mg qd versus clomiphene citrate (CC) 100mg qd from cycle day 3–7 | Age: Mean (SD): AI group: 33.2 ± 3.3 CC group: 32.7 ± 4.2 Range: 25–41 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: NR Endometriosis: NR Male factor: NR Tubal factor: NR PCOS: NR Other (specify): Primary infertility: 22 (67%) Secondary infertility: 11 (33%) Inclusion criteria:; - Primary or secondary infertility < 1 year; Exclusion criteria:; - Bilateral tubal obstruction diagnosed by either HSG or laparoscopy; - Severe male-factor infertility; - Pre-existing ovarian cysts at US on cycle day 3; - Day 3 blood estradiol ≥ 100pmol/l or FSH ≥ 10 IU/l; - + βhCG; - Before enrollment:; 1 No use of OCP or CC within 1 month; 2 No use of gonadotropinreleasing hormone agonist within 3 months; 3 No use of depot medroxyprogesterone within 6 months | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy (intention to treat): | | | | Comments:; - Randomization not well-described; “Randomization by computer”; - No allocation concealment; - No discussion regarding blinding; Quality assessment: Randomization method: -, no details Blinding: -, not discussed Dropout rate < 20%: + Adequacy of randomization concealment: -, not discussed
Wu, Wang, Cheng, et al., 2007 #56740 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Wu, Wang, Cheng, et al., 2007 #56740 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Anastrozole | 2 | 12 | 14
Wu, Wang, Cheng, et al., 2007 #56740 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | CC | 0 | 19 | 19
Wu, Wang, Cheng, et al., 2007 #56740 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 2.49 | 31 | 33
Wu, Wang, Cheng, et al., 2007 #56740 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 5.68 | 0.27 | 119.72
Yarali, Yildiz, Demirol, et al., 2002 #2820 | Geographical location: Ankara, Turkey Study dates: NR Size of population: Recruited 32, 16 to metformin, 16 to placebo. 6 removed from metformin due to ovulation, 1 removed from placebo due to ovulation. Final number receiving FSH: Metformin: 10 Placebo: 15 Number of cycles analyzed: 25 Number of cycles per patient: 1.00 Study type: RCT Interventions: Compares pregnancy rates and biochemical changes in women treated with metformin or placebo for 6 wk followed by rFSH. | Age: Mean (SD): Metformin: 29.7 ± 5.6 Placebo: 28.4 ± 5.1 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 32 (100%) Inclusion criteria:; - PCOS by clinical, biochemical and ultrasound criteria; - Refractory to previous CC for 6 mo; - Normal HSG or laparoscopy within 6 mo; - Normal glucose tolerance by OGTT; Exclusion criteria:; - Previous gonadotropin treatment; - Diabetes, CAH, Cushings, hyperprolactinemia, hypothyroid, or any other infertility factor; - Previous genital surgery | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | 1) Total pregnancy rate in the 2 grps including observation time and 1 cycle rFSH: | | | | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Met | 5 | 11 | 16 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Placebo | 1 | 14 | 15 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Total | 6 | 25 | 31 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Rel risk | 4.69 | 0.62 | 35.63 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | 2) Pregnancy rate in the observation period prior to rFSH: | | | | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Met | 2 | 4 | 6 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Placebo | 0 | 1 | 1 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Total | 2 | 5 | 7 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.43 | 0.11 | 19.20 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | 3) Pregnancy rate with 1 cycle rFSH: | | | | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Met | 3 | 7 | 10 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Placebo | 1 | 14 | 15 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Total | 4 | 21 | 25 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Rel risk | 4.50 | 0.54 | 37.38 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | 4) Spontaneous ovulation rate prior to rFSH: | | | | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | | Ovul + | Ovul - | Total | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Met | 6 | 10 | 16 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Placebo | 1 | 15 | 16 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Total | 7 | 25 | 32 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Rel risk | 6.00 | 0.81 | 44.35 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | 5) Ovulation rate with rFSH: | | | | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | | Ovul + | Ovul - | Total | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Met | 9 | 1 | 10 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Placebo | 11 | 4 | 15 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | Total | 20 | 5 | 25 | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Yarali, Yildiz, Demirol, et al., 2002 #2820 | | | Definition(s) of outcome(s): Pregnancy: + hcg Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comment: Low numbers Quality assessment: Randomization method: - (NR) Blinding: - (NR) Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Rel risk | 1.23 | 0.85 | 1.77
Yilmaz, Kelekci, Savan, et al., 2006 #56800 | Geographical location: Ankara, Turkey Study dates: May 2002–Apr 2004 Size of population (no. of patients): 133 Number of cycles analyzed: 1 cycle per patient and 8 lost to f/u, so 125 cycles Number of cycles per patient: 1 Study type: RCT Interventions: Population: Women with WHO class II anovulation Group A: 50 mg CC on days 5–9 Group B: 50 mg CC plus hCG (Pregnyl 10,000 IU IM) when 1 or more follicles reached 18 mm | Age: Mean (SD): Group A: 26.7 ± 3.2 Group B: 26.2 ± 3.4 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100% Inclusion criteria:; - WHO class II ovarian dysfunction; - Normal prolactin; - Normal gonadotropins; - Primary infertility with oligo/amenorrhea; - Ages 20–40; - Primary infertility 2 years; - No h/o ovulation induction treatment and thyroid disease; - Normal HSG; - Normal semen analysis; Exclusion criteria: See above | Definition(s) of outcome(s): Clinical pregnancy: + hCG and +FH on US at 7 weeks Live birth: NR Multiples: Yes Complications: NR | 1) Pregnancy: | | | | Comments:; - Unable to calculate intention-to-treat. 8 lost to follow-up but no information regarding the distribution of these patients.; - Only group B received hCG IM, affecting blinding; - Ultrasonographers were blinded; Quality assessment: Randomization method: + Blinding: - (only group B received hCG) Dropout rate < 20%: + (6% [8/133]) Adequacy of randomization concealment: +
Yilmaz, Kelekci, Savan, et al., 2006 #56800 | | | Definition(s) of outcome(s): Clinical pregnancy: + hCG and +FH on US at 7 weeks Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg -
Yilmaz, Kelekci, Savan, et al., 2006 #56800 | | | Definition(s) of outcome(s): Clinical pregnancy: + hCG and +FH on US at 7 weeks Live birth: NR Multiples: Yes Complications: NR | CC+hCG | 20 | 40 | 60
Yilmaz, Kelekci, Savan, et al., 2006 #56800 | | | Definition(s) of outcome(s): Clinical pregnancy: + hCG and +FH on US at 7 weeks Live birth: NR Multiples: Yes Complications: NR | CC only | 18 | 47 | 65
Yilmaz, Kelekci, Savan, et al., 2006 #56800 | | | Definition(s) of outcome(s): Clinical pregnancy: + hCG and +FH on US at 7 weeks Live birth: NR Multiples: Yes Complications: NR | | 38 | 87 | 125
Yilmaz, Kelekci, Savan, et al., 2006 #56800 | | | Definition(s) of outcome(s): Clinical pregnancy: + hCG and +FH on US at 7 weeks Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Yilmaz, Kelekci, Savan, et al., 2006 #56800 | | | Definition(s) of outcome(s): Clinical pregnancy: + hCG and +FH on US at 7 weeks Live birth: NR Multiples: Yes Complications: NR | Rel risk | 1.20 | 0.71 | 2.05
Yilmaz, Kelekci, Savan, et al., 2006 #56800 | | | Definition(s) of outcome(s): Clinical pregnancy: + hCG and +FH on US at 7 weeks Live birth: NR Multiples: Yes Complications: NR | 2) Twin gestation:
Yilmaz, Kelekci, Savan, et al., 2006 #56800 | | | Definition(s) of outcome(s): Clinical pregnancy: + hCG and +FH on US at 7 weeks Live birth: NR Multiples: Yes Complications: NR | | Twin + | Twin -
Yilmaz, Kelekci, Savan, et al., 2006 #56800 | | | Definition(s) of outcome(s): Clinical pregnancy: + hCG and +FH on US at 7 weeks Live birth: NR Multiples: Yes Complications: NR | CC+hCG | 2 | 58 | 60
Yilmaz, Kelekci, Savan, et al., 2006 #56800 | | | Definition(s) of outcome(s): Clinical pregnancy: + hCG and +FH on US at 7 weeks Live birth: NR Multiples: Yes Complications: NR | CC only | 1 | 64 | 65
Yilmaz, Kelekci, Savan, et al., 2006 #56800 | | | Definition(s) of outcome(s): Clinical pregnancy: + hCG and +FH on US at 7 weeks Live birth: NR Multiples: Yes Complications: NR | | 3 | 122 | 125
Yilmaz, Kelekci, Savan, et al., 2006 #56800 | | | Definition(s) of outcome(s): Clinical pregnancy: + hCG and +FH on US at 7 weeks Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 2.17 | 0.20 | 23.29

Evidence Table 2. Question 3 - Assisted Conception: IVF and ICSI

Study | Study Design | Patients | Clinical Presentation | Results | | | | Comments/Quality Scoring
Aboulghar, Mansour, Serour, et al., 2004 #12050 | Geographical location: Cairo, Egypt Study dates: 2002 Size of population: 151 Number of cycles analyzed: 151 Number of cycles per patient: 1 Study type: RCT Interventions: Investigated whether increasing the dose of gonadotrophins on the date of GnRH antagonist administer would increase the pregnancy rate. The study grp received an extra dose of 75 units per day from the date of GnRH antagonist (Cetrorllixix) administer until TVOR. Randomization at time of study intervention with sealed envelopes | Age: Mean (SD): Control: 31.9 (6.1) Study group: 32.8 (5.1) Race/ethnicity (n [%]): Egyptian 100% Diagnoses (n [%]): NR Inclusion criteria:; - Female; - Age < 40; - Infertility; Exclusion criteria:; - History of poor responses; - General contraindication for pregnancy; - Clinically significant systemic disease; - More than 3 failed cycles | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | 1) Clinical pregnancy rate: | | | | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Aboulghar, Mansour, Serour, et al., 2004 #12050 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | Note: numbers imputed from reported rates | | | | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Aboulghar, Mansour, Serour, et al., 2004 #12050 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Aboulghar, Mansour, Serour, et al., 2004 #12050 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | Standard + 75 | 29 | 50 | 79 | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Aboulghar, Mansour, Serour, et al., 2004 #12050 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | Standard | 23 | 49 | 72 | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Aboulghar, Mansour, Serour, et al., 2004 #12050 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | | 52 | 99 | 151 | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Aboulghar, Mansour, Serour, et al., 2004 #12050 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Aboulghar, Mansour, Serour, et al., 2004 #12050 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | Rel risk | 1.15 | 0.74 | 1.79 | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Aboulghar, Mansour, Serour, et al., 2004 #12050 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | 2) Multiple pregnancy rate: | | | | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Aboulghar, Mansour, Serour, et al., 2004 #12050 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | Note: numbers imputed from reported rates | | | | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Aboulghar, Mansour, Serour, et al., 2004 #12050 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | | Multiples | Singleton | | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Aboulghar, Mansour, Serour, et al., 2004 #12050 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | Standard + 75 | 11 | 18 | 29 | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Aboulghar, Mansour, Serour, et al., 2004 #12050 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | Standard | 9 | 14 | 23 | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Aboulghar, Mansour, Serour, et al., 2004 #12050 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | | 20 | 32 | 52 | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Aboulghar, Mansour, Serour, et al., 2004 #12050 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of fetal cardiac activity 3 wks after embryo transfer Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Unclear if reported analysis was intent-to-treat Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.97 | 0.49 | 1.93
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | Geographical location: Brussels, Belgium; Lubeck and Frankfurt, Germany Study dates: NR Size of population: 273 Number of cycles analyzed: 273 Number of cycles per patient: 1 Study type: RCT Interventions: Compared the use of GnRH agonist (buserelin) and GnRH antagonist (cetrorelix) in ovarian stimulation with HMG | Age: Mean (SD): Cetrorelix: 31.9 (3.7) Buserelin: 31.6 (3.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age ≤ 39; - Regular menstrual cycle ranging 24d–35d; - Normal ovarian function (detected by FSH ≤ 10 IU/L); - Normal ovarian morphology; - Normal uterus; - No more than three previous IVF or ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Clinical Pregnancy: u/s showed gestational sac and fetus with cardiac activity Live birth: NR Multiples: Yes Complications: Miscarriage, ectopic pregnancies, OHSS (using WHO criteria OHSS II: Moderate OHSS III: Severe) | 1) Clinical pregnancy rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Cetrorelix | 42 | 146 | 188 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Buserelin | 22 | 66 | 88 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | | 64 | 212 | 276 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Rel risk | 0.89 | 0.57 | 1.40 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | 2) Number of deliveries (patients): | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | | Del + | Del - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Cetrorelix | 34 | 154 | 188 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Busereln | 19 | 69 | 88 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | | 53 | 223 | 276 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Rel risk | 0.84 | 0.51 | 1.38 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | 3) Outcomes of all pregnancies: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | | [underlined: Cetrorelix] | [underlined: Buserelin] | [underlined: P-value] | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Clinical preg | 42 | 22 | NS | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Miscarriage | 7 | 2 | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Ectopic preg | 1 | 0 | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | No of deliveries | 34 | 19 | NS | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Singletons | 26 | 17 | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Twins | 8 | 2 | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | No. children born | 42 | 21 | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | 4) OHSS rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | | OHSS + | OHSS - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Cetrorelix | 2 | 186 | 188 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Buserelin | 5 | 80 | 85 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Total | 7 | 266 | 273 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | Rel risk | 0.18 | 0.04 | 0.91 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | 5) One pt in Buserelin group had severe OHSS | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Albano, Felberbaum, Smitz, et al., 2000 #8590 and Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) | | | | 6) 3 (1.6%) pts in Cetrorelix and 6 (5.9%) in Buserelin grp did not get hCG trigger due to threatened OHSS. | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Significantly higher E2 on the date of hCG trigger was noted in Buserelin grp.
Alleyassin, Khademi, Aghahosseini, Safdarian, et al., 2006 #50130 | Geographical location: Tehran, Iran Study dates: January 2004 to January 2005 Size of population (no. of patients): 160 Number of cycles analyzed: 160 Number of cycles per patient: 1 Study type: RCT Interventions: Bilateral transfer of injected oocytes into fallopian tubes Unilateral transfer of injected oocytes into fallopian tube | Age: Mean (SD): 30 (4.3) Range: 16 – 39 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 160 (100%) Inclusion criteria: Female < 40 years old; primary infertility; male factor infertility (the candidate couples for percutaneous epididymal sperm aspiration or testicular sperm extraction were not allowed to enter to the study); basal levels of FSH ≤ 10 IU/L and basal levels of E2 < 80 pg/mL at the initiation of the ovarian stimulation, and > 4 metaphase 2 (MII) normal-shaped oocytes obtained by ovum puncture. Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Pregnancy was defined by the detection of a positive serum β-hCG (≥ 200 mIU/mL) 18–19 days after MIFT. Clinical intrauterine pregnancy was confirmed by detection of a gestational sac in the uterus 2–3 weeks later by transvaginal ultrasound. Live birth: NR Multiples: Yes Complications: Pregnancy with unknown location: either a discriminatory zone ≥ 1,500 mIU/mL of serum hCG level or a suboptimally rising serum hCG over 48 hours | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Alleyassin, Khademi, Aghahosseini, Safdarian, et al., 2006 #50130 | | | | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Alleyassin, Khademi, Aghahosseini, Safdarian, et al., 2006 #50130 | | | | Bilateral transfer | 32 | 48 | 80 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Alleyassin, Khademi, Aghahosseini, Safdarian, et al., 2006 #50130 | | | | Unilateral transfer | 40 | 40 | 80 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Alleyassin, Khademi, Aghahosseini, Safdarian, et al., 2006 #50130 | | | | Total | 72 | 88 | 160 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Alleyassin, Khademi, Aghahosseini, Safdarian, et al., 2006 #50130 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Alleyassin, Khademi, Aghahosseini, Safdarian, et al., 2006 #50130 | | | | Rel risk | 0.80 | 0.57 | 1.13 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Alleyassin, Khademi, Aghahosseini, Safdarian, et al., 2006 #50130 | | | | 2) Clinical intrauterine pregnancy | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Alleyassin, Khademi, Aghahosseini, Safdarian, et al., 2006 #50130 | | | | Same as pregnancy. | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Alleyassin, Khademi, Aghahosseini, Safdarian, et al., 2006 #50130 | | | | 3) Multiples: Bilateral, 4 multiples in 32 pregnancies; unilateral, 7 multiples in 40 pregnancies. | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
4) One pregnancy of unknown location in each group
Anderson, Devroey, and Arce, 2006 #50170 | Geographical location: 37 centers in Belgium, France, Finland, Czech Republic, Poland, Denmark, Sweden, Israel, Slovenia Spain Study dates: Feb 2004–Dec 2004 Size of population (no. of patients): 731 Number of cycles analyzed: 731 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - Long protocol GnRH agonist, randomized to either highly purified human menopausal gonadotropin (HP-hmG) or recombinant FSH (rFSH), both with standard dose of 225 IU s.c for 1^st^ 5 days, adjusted afterwards to maximum of 450 IU daily dose and 20 days maximum duration of treatment; - 1–2 embryos transferred | Age: Mean (SD): HP-hMG: 30.8 (3.2), rFSH 30.9 (3.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 317 (43.4%) Male factor:86 (11.6%) Tubal factor: 256 (35.0%) Other (specify): (includes endometriosis) 72 (9.8%) Inclusion criteria:; (i) women with good physical and mental health, aged 21–37 years with regular menstrual cycles of 21–35 days and presumed to be ovulatory;; (ii) tubal or unexplained infertility, including endometriosis stage I/II and mild male factor, eligible for IVF treatment;; (iii) infertility for ≥1 year before randomization, except for proven bilateral tubal infertility;; (iv) BMI of 18–29 kg/m2 at the time of randomization;; (v) hysterosalpingography, hysteroscopy or transvaginal ultrasound documenting a uterus consistent with expected normal function (e.g. no clinically interfering uterine fibroids) within 3 years before randomization;; (vi) transvaginal ultrasound documenting the presence of both ovaries, without evidence of abnormality (e.g. no endometrioma) and normal adnexa (e.g. no hydrosalpinx) within 6 months before randomization;; (vii) early follicular phase serum FSH levels of 1–12 IU/l;; (viii) willing to accept transfer of one or two embryos;; (ix) male partner with sperm quality compatible with fertilization via IVF procedure (results obtained within 12 months before randomization) or previous clinical pregnancy;; (x) confirmation of down-regulation before randomization, defined as either menstrual bleeding and transvaginal ultrasound showing a shedded endometrium with a thickness of < 5 mm and no ovarian cysts or serum estradiol (E2) levels of < 50 pg/ml (local laboratory) and transvaginal ultrasound showing no ovarian cysts;; (xi) signed informed consent form before screening.; Exclusion criteria:; (i) polycystic ovarian syndrome, endometriosis stage III/IV or severe male factor requiring ICSI;; (ii) more than three previously consecutive unsuccessful IVF cycles;; (iii) previous poor response in an IVF cycle, defined as >20 days of gonadotrophin stimulation, cancellation due to limited follicular response or less than four follicles of ≥15 mm diameter;; (iv) previous IVF cycle with unsuccessful fertilization, defined as fertilization of ≤30% of the retrieved oocytes;; (v) history of recurrent miscarriage;; (vi) severe ovarian hyperstimulation syndrome (OHSS) in a previous IVF cycle;; (vii) any significant systemic disease, endocrine or metabolic abnormalities (pituitary, thyroid, adrenal, pancreas, liver or kidney);; (viii) use of any non-registered investigational drug during the 3 months before screening or previous participation in the study and any concomitant medication that would interfere with the evaluation of the study medication (non-study hormonal therapy, except thyroid medication, anti-psychotics, anxiolytics, hypnotics, sedatives and need for continuous use of prostaglandin inhibitors);; (ix) treatment with clomiphene citrate, metformin, gonadotrophins or GnRH analogues within 1 month before randomization;; (x) pregnancy, lactation or contraindication to pregnancy;; (xi) current or past (3 months) smoking habit of >10 cigarettes per day;; (xii) current or past (last 12 months) abuse of alcohol or drugs;; (xiii) a history of chemotherapy (except for gestational conditions) or radiotherapy;; (xiv) undiagnosed vaginal bleeding;; (xv) tumours of the ovary, breast, adrenal gland, pituitary or hypothalamus and malformation of sexual organs incompatible with pregnancy and; (xvi) hypersensitivity to any trial product. | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: at least 1 viable fetus 10–11 weeks after embryo transfer Live birth: At least one live born neonate Multiples: Yes Complications: Moderate/severe OHSS | 1) Ongoing pregnancy (intention-to-treat): | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | hMG | 97 | 266 | 363 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | rFSH | 82 | 286 | 368 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | | 179 | 552 | 731 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | Rel risk | 1.20 | 0.93 | 1.55 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | hMG | 96 | 267 | 363 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | rFSH | 82 | 286 | 368 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | | 178 | 553 | 731 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | Rel risk | 1.19 | 0.92 | 1.53 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | 3) Moderate/severe OHSS: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | hMG | 8 | 355 | 363 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | rFSH | 8 | 360 | 368 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | | 16 | 715 | 731 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Anderson, Devroey, and Arce, 2006 #50170 | | | | Rel risk | 1.01 | 0.38 | 2.67 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
4) Singleton delivery rates similar (21% HP-hMG, 17% rFSH):
Ata, Isiklar, Balaban, et al., 2007 #50290 | Geographical location: Istanbul, Turkey Study dates: April–May 2006 Size of population (no. of patients): 260 Number of cycles analyzed: 260 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to Labotect (stiff outer sheath, no need for stylet) or Wallace embryo transfer catheter | Age: Mean (SD): Wallace: 33.2 (3.7) Labotect: 33.5 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 29 (11%) Endometriosis: 18 (7%) Male factor: 142 (55%) Tubal factor: 33 (13%) Other: “Ovarian factor” 38 (15%) Inclusion criteria: 1^st^ ART cycle Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Visualization of a gestational sac by ultrasound at 4–6 weeks after embryo transfer Ongoing: Viable pregnancy after 20 weeks Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy (ITT): | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: Adequacy of randomization concealment: +
Ata, Isiklar, Balaban, et al., 2007 #50290 | | | | | Preg+ | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: Adequacy of randomization concealment: +
Ata, Isiklar, Balaban, et al., 2007 #50290 | | | | Labotect | 45 | 85 | 130 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: Adequacy of randomization concealment: +
Ata, Isiklar, Balaban, et al., 2007 #50290 | | | | Wallace | 58 | 72 | 130 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: Adequacy of randomization concealment: +
Ata, Isiklar, Balaban, et al., 2007 #50290 | | | | Total | 103 | 157 | 260 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: Adequacy of randomization concealment: +
Ata, Isiklar, Balaban, et al., 2007 #50290 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: Adequacy of randomization concealment: +
Ata, Isiklar, Balaban, et al., 2007 #50290 | | | | Rel risk | 0.78 | 0.57 | 1.05 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: Adequacy of randomization concealment: +
Ata, Isiklar, Balaban, et al., 2007 #50290 | | | | 2) Ongoing pregnancy (ITT): | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: Adequacy of randomization concealment: +
Ata, Isiklar, Balaban, et al., 2007 #50290 | | | | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: Adequacy of randomization concealment: +
Ata, Isiklar, Balaban, et al., 2007 #50290 | | | | Labotect | 36 | 94 | 130 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: Adequacy of randomization concealment: +
Ata, Isiklar, Balaban, et al., 2007 #50290 | | | | Wallace | 50 | 80 | 130 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: Adequacy of randomization concealment: +
Ata, Isiklar, Balaban, et al., 2007 #50290 | | | | Total | 86 | 174 | 260 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: Adequacy of randomization concealment: +
Ata, Isiklar, Balaban, et al., 2007 #50290 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: Adequacy of randomization concealment: +
Rel risk | 0.72 | 0.51 | 1.02
Avrech, Orvieto, Pinkas, et al., 2004 #11000 | Geographical location: Tel Aviv, Israel Study dates: NR Size of population (no. of patients): 219 Number of cycles analyzed: 219 (11 cycles cancelled, not analyzed in paper) Number of cycles per patient: 1.0 Study type: RCT Interventions:; - Short protocol COH; - All had hMG; - Randomized to; (a) hMG only; (b) hMG plus buserelin 200 micrograms 3×/day; (c) hMG plus buserelin 300 micrograms/day; from cycle day 2 until injection of hCG | Age: Mean (SD): 42.0 (2.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - 40–48 years; - normal menstrual cycles; - normal hormonal profile; - normal ultrasound; Exclusion criteria: NR | Definition(s) of outcome(s): Clinical pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 1) Clinical pregnancy, both GnRH agonist groups vs control (data not provided for individual groups): | | | | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Avrech, Orvieto, Pinkas, et al., 2004 #11000 | | | Definition(s) of outcome(s): Clinical pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Avrech, Orvieto, Pinkas, et al., 2004 #11000 | | | Definition(s) of outcome(s): Clinical pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | GnRH a | 11 | 135 | 146 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Avrech, Orvieto, Pinkas, et al., 2004 #11000 | | | Definition(s) of outcome(s): Clinical pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Control | 8 | 65 | 73 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Avrech, Orvieto, Pinkas, et al., 2004 #11000 | | | Definition(s) of outcome(s): Clinical pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | 19 | 200 | 219 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Avrech, Orvieto, Pinkas, et al., 2004 #11000 | | | Definition(s) of outcome(s): Clinical pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Avrech, Orvieto, Pinkas, et al., 2004 #11000 | | | Definition(s) of outcome(s): Clinical pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.69 | 0.29 | 1.63 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Avrech, Orvieto, Pinkas, et al., 2004 #11000 | | | Definition(s) of outcome(s): Clinical pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 2) Live birth, both GnRH agonist groups vs control: | | | | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Avrech, Orvieto, Pinkas, et al., 2004 #11000 | | | Definition(s) of outcome(s): Clinical pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Avrech, Orvieto, Pinkas, et al., 2004 #11000 | | | Definition(s) of outcome(s): Clinical pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | GnRH a | 7 | 139 | 146 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Avrech, Orvieto, Pinkas, et al., 2004 #11000 | | | Definition(s) of outcome(s): Clinical pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Control | 3 | 70 | 73 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Avrech, Orvieto, Pinkas, et al., 2004 #11000 | | | Definition(s) of outcome(s): Clinical pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | 10 | 209 | 219 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Avrech, Orvieto, Pinkas, et al., 2004 #11000 | | | Definition(s) of outcome(s): Clinical pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Rel risk | 1.17 | 0.31 | 4.38
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | Geographical location: Beer-Sheva, Israel Study dates: Apr 2004 to Jan 2005 Size of population (no. of patients): 28 Number of cycles analyzed: 28 Number of cycles per patient: 1.0 Study type: RCT Interventions: rHCG: Recombinant HCG (Ovitrelle 250 μg, Serono) GnRH agonist: (Decapeptyl 0.2 mg, Ferring Ltd, Herzliya, Israel). | Age: Mean (SEM): 30 (1.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 28 [100%] Inclusion criteria: PCOS (diagnosed as 10 or more follicles with a diameter of < 9 mm, Adams et al., 1985) undergoing IVF treatment Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | GnRH | 5 | 10 | 15 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | rHCG | 4 | 9 | 13 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | Total | 9 | 19 | 28 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | Rel risk | 1.08 | 0.37 | 3.21 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | | Live birth + | Live birth - | Total | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | GnRH | 1 | 14 | 15 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | rHCG | 2 | 11 | 13 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | Total | 3 | 25 | 28 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | Rel risk | 0.43 | 0.04 | 4.25 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | One live birth of twins in the GnRH group. | | | | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | 3) OHSS: | | | | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | | OHSS + | OHSS - | Total | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | GnRH | 0 | 15 | 15 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | rHCG | 4 | 9 | 13 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | Total | 4 | 24 | 28 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Babayof, Margalioth, Huleihel, et al., 2006 #50320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: Yes Complications: Moderate to severe OHSS, not defined | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.10 | 0.01 | 1.65
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | Geographical location: Istanbul, Turkey and Haifa, Israel Study dates: Nov 2001–Nov 2002 Size of population (no. of patients): 148 Number of cycles analyzed: 129 cycles secondary to drop out Number of cycles per patient: 1 Study type: RCT Interventions: Population: Women with PCOS undergoing controlled ovarian hyperstimulation (COH) for assisted reproductive technology (ART) Compare gonadrotropin-releasing hormone antagonists (Cetrorelix) versus agonists (leuprolide acetate (LA)) All patients OCP for 21 days LA 0.5 mg daily on starting on day 14. Gonadotropins on day 3. LA dropped to 0.25 mg when gonadotropins started. Gonadotropin dose fixed for first 4 days and then adjusted according to response. When at least 2 follicles reached 18 mm, hCG given. Cetrorelix: gonadotropins on day 3 as above. Cetrorelix 0.25 mg/d s.c. given when leading follicle 14 mm. Cetrorelix continued daily until hCG injection. | Age: Mean (SD): LA: 29.4 ± 4.3 Cetrorelix: 30.1 ± 4.8 Median: LA: 29 Cetrorelix: 30 Range: LA: 21–38 Cetrorelix: 21–38 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 148 (100%) Other: 61(41%) of partners had oligasthenoteratospermia as coexisting infertility factor Inclusion criteria:; - PCOS defined as primary infertility, oligomenorrhea, clinical hyperandrogenism (hirsutism Feriman-Galwey score > 7), reversed FSH/LH ratio, polycystic appearance of ovaries on US; - No previous ART; Exclusion criteria:; - Male factor due to nonobstructive azoospermia; - Hyperprolactinemia; - Thyroid abnormalities | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | 1) Pregnancy (intention-to-treat): | | | | Comments:; - No intention-to-treat analysis; - LA vs. Cetrorelix regimens were different affecting blinding; - No information regarding allocation concealment; Quality assessment: Randomization method: + Blinding: - (different regimens for 2 groups) Dropout rate < 20%: + (12.8% [19/148] total; 6.6% [5/75] from LA group and 19.1% [14/73] from Cetrorelix group) Adequacy of randomization concealment: - (not discussed)
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | | Preg + | Preg -
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | Cetrorelix | 34 | 39 | 73
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | LA | 41 | 34 | 75
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | | 75 | 73 | 148
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | | | Lower 95% CI | Upper 95 % CI
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | Rel risk | 0.85 | 0.62 | 1.17
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | 2) Multiple gestation (intention-to-treat):
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | | Multi + | Multi -
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | Cetrorelix | 20 | 53 | 73
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | LA | 22 | 53 | 75
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | | 42 | 106 | 148
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | | | Lower 95% CI | Upper 95 % CI
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | Rel risk | 0.93 | 0.56 | 1.56
Bahceci, Ulug, Ben-Shlomo, et al., 2005 #10400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac and fetal heart activity on US Live birth: NR Multiples: Yes Complications: OHSS (not defined), miscarriage (not defined) | 3) No difference in OHSS (7.1% LA vs. 5.0% Cetrorelix)
4) No difference in miscarriage (12.1% LA vs. 5.8% Cetrorelix)
Bahceci, Ulug, Ciray, et al., 2006 #50340 | Geographical location: Istanbul, Turkey Study dates: June 2004–Dec 2004 Size of population (no. of patients): 272 Number of cycles analyzed: 272 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to; (a) embryo assessment and transfer day 2, or; (b) embryo assessment and transfer day 3 | Age: Mean (SD): Day 2:36.5 (0.8); Day 3: 36.6 (0.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 53 (19.6%) Male factor: 66 (24.3%) Other (specify): “Female”: 131 (48.3%) Combined: 31 (11.4%) Inclusion criteria:; - Undergoing COH, with ≤5 oocytes; - Fresh ejaculated semen; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | 1) Clinical pregnancy: | | | | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Day 2 | 51 | 86 | 137 | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Day 3 | 29 | 106 | 135 | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | 80 | 192 | 272 | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Rel risk | 1.73 | 1.17 | 2.56 | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | 2) Ongoing pregnancy: | | | | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Day 2 | 38 | 99 | 137 | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Day 3 | 22 | 113 | 135 | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | 60 | 212 | 272 | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Rel risk | 1.70 | 1.07 | 2.72 | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | 3) Multiple pregnancy: | | | | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Day 2 | 9 | 42 | 51 | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Day 3 | 7 | 22 | 29 | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | 16 | 64 | 80 | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bahceci, Ulug, Ciray, et al., 2006 #50340 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with increasing hCG Ongoing pregnancy: Viable beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Powered to detect 15% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.73 | 0.30 | 1.76
Balaban, Yakin, Isiklar, et al., 2007 #50410 | Geographical location: Istanbul, Turkey Study dates: Mar 2004–May 2005 Size of population (no. of patients): 396 frozen cycles, thawing in 197 (not explict whether # couples = # cycles) Number of cycles analyzed: 197 Number of cycles per patient: 1.0? Study type: RCT Interventions: Cryopreservation of embryos using either; (a) conventional or; (b) high-security straws (HSS) (designed to prevent cross-contamination), followed by thawing and embryo transfer | Age: Mean (SD): Conventional 32.1 (3.3); HSS: 31.8 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Diagnoses for all frozen cycles (thawed cycles not reported): Unexplained infertility: 16 (4.0%) Male factor: 173 (43.7%) Combined: 107 (27.0%) Inclusion criteria: NR Exclusion criteria: Testicular sperm extraction, percutaneous epididymal aspiration | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: Yes (twins) Complications: NR | 1) Clinical pregnancy: | | | | Comments: Unclear whether # cycles/patient = 1; 92 (HSS) and 96 (conventional) cycles reported as not Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Balaban, Yakin, Isiklar, et al., 2007 #50410 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: Yes (twins) Complications: NR | | Preg + | Preg -
Balaban, Yakin, Isiklar, et al., 2007 #50410 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: Yes (twins) Complications: NR | HSS | 43 | 57 | 100
Balaban, Yakin, Isiklar, et al., 2007 #50410 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: Yes (twins) Complications: NR | Control | 30 | 66 | 96
Balaban, Yakin, Isiklar, et al., 2007 #50410 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: Yes (twins) Complications: NR | | 73 | 123 | 196
Balaban, Yakin, Isiklar, et al., 2007 #50410 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: Yes (twins) Complications: NR | | | Lower 95% CI | Upper 95 % CI
Balaban, Yakin, Isiklar, et al., 2007 #50410 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: Yes (twins) Complications: NR | Rel risk | 1.38 | 0.95 | 2.00
Balaban, Yakin, Isiklar, et al., 2007 #50410 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: Yes (twins) Complications: NR | 2) Multiple pregnancies (twins):
Balaban, Yakin, Isiklar, et al., 2007 #50410 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: Yes (twins) Complications: NR | | Twins + | Twins -
Balaban, Yakin, Isiklar, et al., 2007 #50410 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: Yes (twins) Complications: NR | HSS | 18 | 83 | 101
Balaban, Yakin, Isiklar, et al., 2007 #50410 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: Yes (twins) Complications: NR | Control | 5 | 91 | 96
Balaban, Yakin, Isiklar, et al., 2007 #50410 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: Yes (twins) Complications: NR | | 23 | 174 | 197
Balaban, Yakin, Isiklar, et al., 2007 #50410 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: Yes (twins) Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 3.42 | 1.32 | 8.85
Balasch, Creus, Fabregues, et al., 2001 #58030 | Geographical location: Barcelona, Spain Study dates: NR Size of population (no. of patients): 30 Number of cycles analyzed: 30 Number of cycles per patient: 1.0 Study type: RCT Interventions: GnRH agonist down-regulation, randomized to rFSH alone or rFSH + fixed dose rLH | Age: Mean (SD): rFSH alone: 33.6 (0.8) rFSH + rLH: 34.8 (0.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 29–40; - Regular menses; - FSH < 11; Exclusion criteria:; - > 2 previous ART attempts; - PCOS | Definition(s) of outcome(s): Pregnancy: NR Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy (per randomized subject): | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Balasch, Creus, Fabregues, et al., 2001 #58030 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Balasch, Creus, Fabregues, et al., 2001 #58030 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: NR Multiples: NR Complications: NR | rFSH + rLH | 0 | 16 | 16 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Balasch, Creus, Fabregues, et al., 2001 #58030 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: NR Multiples: NR Complications: NR | rFSH | 2 | 12 | 14 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Balasch, Creus, Fabregues, et al., 2001 #58030 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: NR Multiples: NR Complications: NR | Total | 2 | 28 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Balasch, Creus, Fabregues, et al., 2001 #58030 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Rel risk | 0.18 | 0.01 | 3.39
Barmat, Chantilis, Hurst, et al., 2005 #10670 | Geographical location: Abington, PA; Dallas, TX; Charlotte, NC; New Orleans, LA Study dates: NR Size of population (no. of patients): 80 Number of cycles analyzed: 80 Number of cycles per patient: 1 Study type: RCT Interventions: Agonist: OC on cycle day 2–4 to day 14–28. About 5 days before completing OCs, leuprolide 0.5 mgm/d started. In 5 days, if adequate pituitary desensitization demonstrated, FSH 300 IU/d SC in the abdominal wall with dose adjusted of 75–150 IU based on patients' response by US and hormonal assay; leuprolide reduced to 0.25 mgm/d. If E2 >pg/mL or a cyst > 20 mm continued leuprolide another week; if E2 still elevated, patient dropped. Antagonist: Same OC regimen; patients with E2 > 60 pg/mL started on FSH. Cancelled if cyst > 20mm. Ganirelix 250 μgm/evening when a follicle obtained of 12–14 mm. | Age: Mean (SD): 32.5 (3.5) Range: 28–38 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples undergoing IVF with or without ICSI, < 39 years, day-3 FSH <=10, E2 <60 pg/mL, basal antral follicle > 5 with a menstrual cycle range of 26 to 34 days, no more than one previous failed IVF or IVF/ICSI cycle, BMI 19 to 32 kg/m2, no hydorsalpinx by hysterosalpingogram, laparoscopy or ultrasound in previous year, nonobstructive azoospermia Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Biochemical based on β-hCG measured 14 dys after oocyte retrieval; “ongoing” based on U/S at 6 weeks with sacs with fetal heart motion. Live birth: NR Multiples: NR Complications: NR | 1) Delivered pregnancy: | | | | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | Antagonist | 12 | 26 | 38 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | Agonistt | 17 | 24 | 41 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | | 29 | 50 | 79 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | Rel risk | 0.76 | 0.42 | 1.38 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | Excludes one pregnancy at 37 weeks. | | | | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | 2) Biochemical pregnancy: | | | | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | Antagonist | 14 | 25 | 39 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | Agonist | 18 | 23 | 41 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | | 32 | 48 | 80 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | Rel risk | 0.82 | 0.47 | 1.41 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | 3) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | | Ongoing preg + | Ongoing preg - | Total | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | Antagonist | 14 | 25 | 39 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | Agonist | 18 | 23 | 41 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | | 32 | 48 | 80 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Barmat, Chantilis, Hurst, et al., 2005 #10670 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: + Adequacy of randomization concealment: - (open label)
Rel risk | 0.82 | 0.47 | 1.41
Baruffi, Mauri, Petersen, et al., 2000 #58050 | Geographical location: Sao Paolo, Brazil Study dates: NR Size of population (no. of patients): 103 Number of cycles analyzed: 103 Number of cycles per patient: 1.0 Study type: RCT Interventions: ICSI; randomized to laser zona thinning or no zona thinning | Age: Mean (SD): Zona thinning: 31.8 (3.6) No thinning: 31.4 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 100% Inclusion criteria:; - Age ≤ 37; - Scheduled for ICSI for male factor; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2000 #58050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2000 #58050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Zona thinning | 17 | 34 | 51 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2000 #58050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | No zona thinning | 21 | 31 | 52 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2000 #58050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 38 | 65 | 103 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2000 #58050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.83 | 0.50 | 1.37
Baruffi, Mauri, Petersen, et al., 2003 #14340 | Geographical location: Sao Paulo, Brazil Study dates: NR Size of population (no. of patients): 103 Number of cycles analyzed: 103 Number of cycles per patient: 1.0 Study type: RCT Interventions: 400 mg vaginal progesterone beginning at (a) day of oocyte retrieval vs (b) day of embryo transfer (day 2) | Age: Mean (SD): Retrieval 34.2 (4.6); transfer: 34.8 (4.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR at 6 weeks Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2003 #14340 | | Age: Mean (SD): Retrieval 34.2 (4.6); transfer: 34.8 (4.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR at 6 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2003 #14340 | | Age: Mean (SD): Retrieval 34.2 (4.6); transfer: 34.8 (4.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR at 6 weeks Live birth: NR Multiples: NR Complications: NR | Day of retrieval | 14 | 37 | 51 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2003 #14340 | | Age: Mean (SD): Retrieval 34.2 (4.6); transfer: 34.8 (4.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR at 6 weeks Live birth: NR Multiples: NR Complications: NR | Day of transfer | 15 | 37 | 52 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2003 #14340 | | Age: Mean (SD): Retrieval 34.2 (4.6); transfer: 34.8 (4.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR at 6 weeks Live birth: NR Multiples: NR Complications: NR | | 29 | 74 | 103 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2003 #14340 | | Age: Mean (SD): Retrieval 34.2 (4.6); transfer: 34.8 (4.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR at 6 weeks Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.95 | 0.51 | 1.76
Baruffi, Mauri, Petersen, et al., 2003 #15470 | Geographical location: Sao Paulo, Brazil Study dates: NR Size of population: 106 Number of cycles analyzed: 106 Number of cycles per patient: 1 Study type: RCT Interventions: Compared implantation and pregnancy rates between day 2 and day 3 embryo transfer after ICSI | Age: Mean (SD): Day 2: 33.1 (4.5) Day 3: 32.7 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Clinical pregnancy: Presence of gestational sac and embryo with a heart beat at 6 wks gestation Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy rate: | | | | Comments: None Quality assessment: Randomization method: + (“randomization list”) Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2003 #15470 | | Age: Mean (SD): Day 2: 33.1 (4.5) Day 3: 32.7 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Clinical pregnancy: Presence of gestational sac and embryo with a heart beat at 6 wks gestation Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | total | Comments: None Quality assessment: Randomization method: + (“randomization list”) Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2003 #15470 | | Age: Mean (SD): Day 2: 33.1 (4.5) Day 3: 32.7 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Clinical pregnancy: Presence of gestational sac and embryo with a heart beat at 6 wks gestation Live birth: NR Multiples: NR Complications: NR | Day 2 | 23 | 30 | 53 | Comments: None Quality assessment: Randomization method: + (“randomization list”) Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2003 #15470 | | Age: Mean (SD): Day 2: 33.1 (4.5) Day 3: 32.7 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Clinical pregnancy: Presence of gestational sac and embryo with a heart beat at 6 wks gestation Live birth: NR Multiples: NR Complications: NR | Day 3 | 22 | 31 | 53 | Comments: None Quality assessment: Randomization method: + (“randomization list”) Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2003 #15470 | | Age: Mean (SD): Day 2: 33.1 (4.5) Day 3: 32.7 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Clinical pregnancy: Presence of gestational sac and embryo with a heart beat at 6 wks gestation Live birth: NR Multiples: NR Complications: NR | Total | 45 | 61 | 106 | Comments: None Quality assessment: Randomization method: + (“randomization list”) Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Baruffi, Mauri, Petersen, et al., 2003 #15470 | | Age: Mean (SD): Day 2: 33.1 (4.5) Day 3: 32.7 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Clinical pregnancy: Presence of gestational sac and embryo with a heart beat at 6 wks gestation Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + (“randomization list”) Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Rel risk | 1.05 | 0.67 | 1.63
Battaglia, Regnani, Marsella, et al., 2002 #2670 | Geographical location: Modena, Italy Study dates: NR Size of population (no. of patients): 37 Number of cycles analyzed: 37 (5 cancellations) Number of cycles per patient: 1.00 Study type: RCT Interventions:; - IVF cycles; - COH with triptorelin, purified FSH; - Randomized to 16 g/day L-arginine (nitric oxide stimulant) or placebo | Age: Mean (SD): 33.8 (3.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Tubal factor: 37 (100%) Inclusion criteria:; - Tubal infertility; - Scheduled for IVF; - Bilateral ovaries; - Normal ovulation; Exclusion criteria:; - Concurrent illness; - BMI>30; - Endometriosis; - Regular exercise; - Smoking > 10 cigs/day; - Hypertension | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Ongoing pregnancy (intention-to-treat): | | | | Comments:; - Study powered on difference in number of follicles >17 mm diameter; - Timing of beginning/end of L-arginine not specified; - Paper states significant difference in pregnancy rates, but difference not statistically significant in either ITT population or analyzed population (n = 32); Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Battaglia, Regnani, Marsella, et al., 2002 #2670 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Battaglia, Regnani, Marsella, et al., 2002 #2670 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Study drug | 3 | 15 | 18
Battaglia, Regnani, Marsella, et al., 2002 #2670 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Control | 6 | 13 | 19
Battaglia, Regnani, Marsella, et al., 2002 #2670 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 9 | 28 | 37
Battaglia, Regnani, Marsella, et al., 2002 #2670 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Battaglia, Regnani, Marsella, et al., 2002 #2670 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.53 | 0.15 | 1.80
Battaglia, Regnani, Marsella, et al., 2002 #2670 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy (as reported in paper):
Battaglia, Regnani, Marsella, et al., 2002 #2670 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Battaglia, Regnani, Marsella, et al., 2002 #2670 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | L-arginine | 3 | 13 | 16
Battaglia, Regnani, Marsella, et al., 2002 #2670 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Placebo | 6 | 10 | 16
Battaglia, Regnani, Marsella, et al., 2002 #2670 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 9 | 23 | 32
Battaglia, Regnani, Marsella, et al., 2002 #2670 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 0.50 | 0.15 | 1.66
Beckers, Laven, Eijkemans, et al., 2000 #58060 | Geographical location: Rotterdam, the Netherlands Study dates: NR Size of population (no. of patients): 60 Number of cycles analyzed: 60 Number of cycles per patient: 1.0 Study type: RCT Interventions:; (a) Long protocol GnRH agonist = hMG + hCG for luteal support;; (b) Cessation of GnRH on day 3 of hMG, no luteal support;; (c) GnRH until hCG for ovarian maturation , no luteal support | Age: Mean: 32–33 in all groups (total for randomized patients not given) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 39; - Scheduled for IVF; - Regular menses; - No hormonal abnormalities; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | 1) Pregnancy (all randomized subjects), GnRH + hMG + luteal support vs. early cessation GnRH: | | | | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | | Preg + | Preg - | Total | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | Early cessation | 3 | 17 | 20 | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | GnRH + support | 4 | 16 | 20 | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | Total | 7 | 33 | 40 | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | | Value | Lower 95% CI | Upper 95% CI | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | Rel risk | 0.75 | 0.19 | 2.93 | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | 2) Pregnancy (all randomized subjects), GnRH + hMG + luteal support vs. no support: | | | | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | | Preg + | Preg - | Total | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | No support | 0 | 20 | 20 | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | GnRH + support | 4 | 16 | 20 | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | Total | 4 | 36 | 40 | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | | Value | Lower 95% CI | Upper 95% CI | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | Rel risk | 0.11 | 0.01 | 1.94 | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | 3) Cancellation for hyper-response: | | | | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Beckers, Laven, Eijkemans, et al., 2000 #58060 | | | Definition(s) of outcome(s): Pregnancy: + pregnancy test Live birth: NR Multiples: NR Complications: Hyper-response | Early cessation vs. standard protocol: 0.71 (0.27, 1.88) | | | | Comments: Subjects withdrawn for hyper-response not included in reported analysis Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
No support vs. standard protocol: 1.43 (0.68, 3.00)
Bellver, Munoz, Ballesteros, et al., 2003 #15060 | Geographical location: Valencia, Spain Study dates: Mar 1999–Feb 2002 Size of population (no. of patients): 988 (605 patients and 383 oocyte donors); only patients reported here Number of cycles analyzed: 605 Number of cycles per patient: 1.0 Study type: RCT Interventions: Albumin: 40 g human albumin Control: No albumin | Age: Mean (SD): 32 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 122 (20%) Inclusion criteria: Collection of > 20 oocytes during oocyte retrieval Exclusion criteria: None specified | Definition(s) of outcome(s): Pregnancy: Pregnancy, biochemical pregnancy, and ongoing pregnancy reported as %, numerator and denominator not defined Live birth: Yes Multiples: NR Complications: OHSS (by Golan et al. 1989 criteria) | 1) Pregnancy (derived from reported percentages): | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bellver, Munoz, Ballesteros, et al., 2003 #15060 | | Age: Mean (SD): 32 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 122 (20%) Inclusion criteria: Collection of > 20 oocytes during oocyte retrieval Exclusion criteria: None specified | | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bellver, Munoz, Ballesteros, et al., 2003 #15060 | | Age: Mean (SD): 32 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 122 (20%) Inclusion criteria: Collection of > 20 oocytes during oocyte retrieval Exclusion criteria: None specified | | Albumin | 138 | 160 | 298 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bellver, Munoz, Ballesteros, et al., 2003 #15060 | | Age: Mean (SD): 32 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 122 (20%) Inclusion criteria: Collection of > 20 oocytes during oocyte retrieval Exclusion criteria: None specified | | No albumin | 166 | 141 | 307 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bellver, Munoz, Ballesteros, et al., 2003 #15060 | | Age: Mean (SD): 32 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 122 (20%) Inclusion criteria: Collection of > 20 oocytes during oocyte retrieval Exclusion criteria: None specified | | Total | 304 | 301 | 605 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bellver, Munoz, Ballesteros, et al., 2003 #15060 | | Age: Mean (SD): 32 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 122 (20%) Inclusion criteria: Collection of > 20 oocytes during oocyte retrieval Exclusion criteria: None specified | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bellver, Munoz, Ballesteros, et al., 2003 #15060 | | Age: Mean (SD): 32 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 122 (20%) Inclusion criteria: Collection of > 20 oocytes during oocyte retrieval Exclusion criteria: None specified | | Rel risk | 0.86 | 0.73 | 1.00 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bellver, Munoz, Ballesteros, et al., 2003 #15060 | | Age: Mean (SD): 32 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 122 (20%) Inclusion criteria: Collection of > 20 oocytes during oocyte retrieval Exclusion criteria: None specified | | 2) OHSS (derived from reported percentages): | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bellver, Munoz, Ballesteros, et al., 2003 #15060 | | Age: Mean (SD): 32 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 122 (20%) Inclusion criteria: Collection of > 20 oocytes during oocyte retrieval Exclusion criteria: None specified | | | OHSS + | OHSS- | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bellver, Munoz, Ballesteros, et al., 2003 #15060 | | Age: Mean (SD): 32 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 122 (20%) Inclusion criteria: Collection of > 20 oocytes during oocyte retrieval Exclusion criteria: None specified | | Albumin | 24 | 274 | 298 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bellver, Munoz, Ballesteros, et al., 2003 #15060 | | Age: Mean (SD): 32 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 122 (20%) Inclusion criteria: Collection of > 20 oocytes during oocyte retrieval Exclusion criteria: None specified | | No albumin | 21 | 286 | 307 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bellver, Munoz, Ballesteros, et al., 2003 #15060 | | Age: Mean (SD): 32 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 122 (20%) Inclusion criteria: Collection of > 20 oocytes during oocyte retrieval Exclusion criteria: None specified | | Total | 45 | 560 | 605 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Bellver, Munoz, Ballesteros, et al., 2003 #15060 | | Age: Mean (SD): 32 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 122 (20%) Inclusion criteria: Collection of > 20 oocytes during oocyte retrieval Exclusion criteria: None specified | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 1.18 | 0.67 | 2.07
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | Geographical location: Tel Aviv, Israel Study dates: Nov 1999 – Apr 2000 Size of population: 349 Number of cycles analyzed: 375 Number of cycles per patient: 1.07 Study type: RCT Interventions: Compares 2 embryo culture systems: P1 Medium by Irvine scientific and the Cook IVF Medium | Age: Mean (SD): P1: 35.2 (6.2) Cook: 35.4 (5.9) Race/ethnicity (n [%]): NR Diagnoses (%): Unexplained infertility: P1: 25.7 Cook: 20.7 Endometriosis and anovulation: P1: 4.5 Cook: 0 Male factor: P1: 27.9 Cook: 35.5 Tubal factor: P1: 27.9 Cook: 19.5 Inclusion criteria:; - Age < 45; - D3 FSH < 12 mIU/mL; - Nl uterine cavity; - Presence of at least 2 follicles ≥ 16 mm in diameter on the day of hCG administration; Exclusion criteria: NR | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | 1) Clinical pregnancy rate: | | | | Comments:; - Randomization by “Table”, but all patients on a given day received intervention; patients with multiple cycles apparently had same media in each cycle; - No a priori sample size estimation; Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | | Preg + | Preg -
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | P1 | 38 | 144 | 182
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | Cook | 23 | 144 | 167
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | | 61 | 288 | 349
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 1.52 | 0.94 | 2.43
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | 2) Live birth:
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | | Preg + | Preg -
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | P1 | 32 | 150 | 182
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | Cook | 20 | 147 | 167
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | | 52 | 297 | 349
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 1.47 | 0.87 | 2.46
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | 2) Multiples:
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | | Preg + | Preg -
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | Study group | 16 | 22 | 38
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | Control | 6 | 14 | 20
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | | 22 | 36 | 58
Ben-Yosef, Amit, Azem, et al., 2004 #10970 | | | Definition(s) of outcome(s): Clinical pregnancy: Presence of a gestational sac, CRL, and fetal heart beat at u/s performed at 6–7 wks after ET Live birth: Yes Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 1.40 | 0.65 | 3.02
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | Geographical location: Antalya, Turkey Study dates: NR Size of population (no. of patients): 240; 180 include in analysis Number of cycles analyzed: 181 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - Embryo transfer on day 2, all under U/S guidance; - All had cervical irrigation with IVF culture media; - Transabdominal U/S used to assess whether any cervical irrigation entered endometrial cavity - subjects excluded if yes; - Flushing group: endometrial cavity irrigated with 0.4 ml culture media under ultrasound guidance; - Embryo transfer | Age (mean [SD]): Flushing: 31.3 (0.5) Control: 31.5 (0.5) Unclear what means were for all randomized Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Women with “difficult transfer, uterine anomalies, or inadvertent flushing of endometrial cavity during cervical irrigation” were excluded after randomization | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy - all randomized: | | | | Comments:; - Much larger number of subjects excluded from flushing arm (n=48), compared to no flushing (n=12); discrepancy this large unlikely to be random; - By intention to treat, flushing significantly worse than no flushing; - Randomization method not specified (“computer-generated”); Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | Flushing | 33 | 87 | 120
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | No Flushing | 56 | 64 | 120
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | | 89 | 151 | 240
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | Efficacy | 0.59 | 0.42 | 0.83
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy - all randomized:
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | | Preg+ | Preg -
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | Flushing | 34 | 86 | 120
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | No Flushing | 51 | 69 | 120
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | | 85 | 155 | 240
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | Efficacy | 0.67 | 0.47 | 0.95
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | 3) Reported rates, based on analyzed patients (n = 73 for flushing, n = 108 for control):
Berkkanoglu, Isikoglu, Seleker, et al., 2006 #50630 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy if positive fetal heart rate on ultrasound Ongoing pregnancy: > 12 weeks gestation Live birth: NR Multiples: NR Complications: NR | Clinical pregnancy: 45.2% flushing, 51.4% control
Ongoing pregnancy: 47.9% flushing, 47.2% control
Bhattacharya, Hamilton, Shaaban, et al., 2001 #4750 | Geographical location: UK (multicenter study) Study dates: NR Size of population: 415 Number of cycles analyzed: 435 Number of cycles per patient: 1.05 Study type: RCT Interventions: Compares the conventional IVF VS ICSI for the treatment of non-male factor infertility | Age: Mean (SD): IVF: 30.9 (4.1) ICSI: 31.6 (3.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: IVF: 21 ICSI: 25 Endometriosis: IVF: 9 ICIS: 7 Male factor (mild) IVF: 11 ICSI: 11 Tubal factor: IVF: 47 ICSI: 48 Ovulation dysfunction: IVF: 9 ICSI: 10 Inclusion criteria:; - Female partner age < 37; - Minimal acceptable semen characteristics; - density 20 millions/ml; - progressive motility 40%; - acceptable morphology per local lab (variable between 10%–20%); Exclusion criteria:; - Fertilization rate in a previous IVF cycle < 20%; - Baseline FSH > 12 mIU/L; - More than 3 previous IVF cycles; - Abnormal semen analysis, require ICSI treatment | Definition(s) of outcome(s): Clinical Pregnancy: Presence of fetal heart activity shown by transvaginal u/s Live birth: NR Multiples: Yes Complications: NR | 1) Clinical pregnancy rate: | | | | Comments:; - 20 couples re-randomized after failure of 1^st^ cycle; - Not true “per-patient” rates; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bhattacharya, Hamilton, Shaaban, et al., 2001 #4750 | | | Definition(s) of outcome(s): Clinical Pregnancy: Presence of fetal heart activity shown by transvaginal u/s Live birth: NR Multiples: Yes Complications: NR | (Note: per cycle, not per patient)
Bhattacharya, Hamilton, Shaaban, et al., 2001 #4750 | | | Definition(s) of outcome(s): Clinical Pregnancy: Presence of fetal heart activity shown by transvaginal u/s Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | Total
Bhattacharya, Hamilton, Shaaban, et al., 2001 #4750 | | | Definition(s) of outcome(s): Clinical Pregnancy: Presence of fetal heart activity shown by transvaginal u/s Live birth: NR Multiples: Yes Complications: NR | IVF | 72 | 147 | 219
Bhattacharya, Hamilton, Shaaban, et al., 2001 #4750 | | | Definition(s) of outcome(s): Clinical Pregnancy: Presence of fetal heart activity shown by transvaginal u/s Live birth: NR Multiples: Yes Complications: NR | ICSI | 53 | 151 | 204
Bhattacharya, Hamilton, Shaaban, et al., 2001 #4750 | | | Definition(s) of outcome(s): Clinical Pregnancy: Presence of fetal heart activity shown by transvaginal u/s Live birth: NR Multiples: Yes Complications: NR | | 125 | 298 | 423
Bhattacharya, Hamilton, Shaaban, et al., 2001 #4750 | | | Definition(s) of outcome(s): Clinical Pregnancy: Presence of fetal heart activity shown by transvaginal u/s Live birth: NR Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Bhattacharya, Hamilton, Shaaban, et al., 2001 #4750 | | | Definition(s) of outcome(s): Clinical Pregnancy: Presence of fetal heart activity shown by transvaginal u/s Live birth: NR Multiples: Yes Complications: NR | Rel risk | 1.27 | 0.94 | 1.71
Bhattacharya, Hamilton, Shaaban, et al., 2001 #4750 | | | Definition(s) of outcome(s): Clinical Pregnancy: Presence of fetal heart activity shown by transvaginal u/s Live birth: NR Multiples: Yes Complications: NR | 2) Multiple pregnancy rate:
Bhattacharya, Hamilton, Shaaban, et al., 2001 #4750 | | | Definition(s) of outcome(s): Clinical Pregnancy: Presence of fetal heart activity shown by transvaginal u/s Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | Total
Bhattacharya, Hamilton, Shaaban, et al., 2001 #4750 | | | Definition(s) of outcome(s): Clinical Pregnancy: Presence of fetal heart activity shown by transvaginal u/s Live birth: NR Multiples: Yes Complications: NR | IVF | 17 | 55 | 72
Bhattacharya, Hamilton, Shaaban, et al., 2001 #4750 | | | Definition(s) of outcome(s): Clinical Pregnancy: Presence of fetal heart activity shown by transvaginal u/s Live birth: NR Multiples: Yes Complications: NR | ICSI | 16 | 37 | 53
Bhattacharya, Hamilton, Shaaban, et al., 2001 #4750 | | | Definition(s) of outcome(s): Clinical Pregnancy: Presence of fetal heart activity shown by transvaginal u/s Live birth: NR Multiples: Yes Complications: NR | | 33 | 92 | 125
Bhattacharya, Hamilton, Shaaban, et al., 2001 #4750 | | | Definition(s) of outcome(s): Clinical Pregnancy: Presence of fetal heart activity shown by transvaginal u/s Live birth: NR Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.78 | 0.44 | 1.40
Bjuresten, Hreinsson, Fridstrom, et al., 2003 #16670 | Geographical location: Stockholm, Sweden Study dates: NR Size of population (no. of patients): 102 Number of cycles analyzed: 102 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - 1 or 2 embryo transfer under ultrasound guidance (no difference in number of embryos, embryo score); - Usually on day 2 (no difference between groups); - Catheters varied, but no difference between groups; - Gynecologist called if midwife unable to complete transfer | Age (mean [SD]): Midwife: 32.8 (3.3) Physician: 33.1 (3.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + heartbeat Live birth: NR Multiples: NR Complications: NR Other: Anonymous questionnaire rating experience | 1) Clinical pregnancy rate: | | | | Comments:; - More ICSI cycles in midwife group (57% vs 41%); - Response rate to questionnaire much higher for midwives; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Bjuresten, Hreinsson, Fridstrom, et al., 2003 #16670 | | Age (mean [SD]): Midwife: 32.8 (3.3) Physician: 33.1 (3.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + heartbeat Live birth: NR Multiples: NR Complications: NR Other: Anonymous questionnaire rating experience | | Preg + | Preg -
Bjuresten, Hreinsson, Fridstrom, et al., 2003 #16670 | | Age (mean [SD]): Midwife: 32.8 (3.3) Physician: 33.1 (3.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + heartbeat Live birth: NR Multiples: NR Complications: NR Other: Anonymous questionnaire rating experience | Midwife | 16 | 35 | 51
Bjuresten, Hreinsson, Fridstrom, et al., 2003 #16670 | | Age (mean [SD]): Midwife: 32.8 (3.3) Physician: 33.1 (3.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + heartbeat Live birth: NR Multiples: NR Complications: NR Other: Anonymous questionnaire rating experience | MD | 15 | 36 | 51
Bjuresten, Hreinsson, Fridstrom, et al., 2003 #16670 | | Age (mean [SD]): Midwife: 32.8 (3.3) Physician: 33.1 (3.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + heartbeat Live birth: NR Multiples: NR Complications: NR Other: Anonymous questionnaire rating experience | | 31 | 71 | 102
Bjuresten, Hreinsson, Fridstrom, et al., 2003 #16670 | | Age (mean [SD]): Midwife: 32.8 (3.3) Physician: 33.1 (3.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + heartbeat Live birth: NR Multiples: NR Complications: NR Other: Anonymous questionnaire rating experience | | | Lower 95% CI | Upper 95 % CI
Bjuresten, Hreinsson, Fridstrom, et al., 2003 #16670 | | Age (mean [SD]): Midwife: 32.8 (3.3) Physician: 33.1 (3.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + heartbeat Live birth: NR Multiples: NR Complications: NR Other: Anonymous questionnaire rating experience | Rel risk | 1.07 | 0.59 | 1.92
2) Proportion of respondents who rated experience “excellent” was similar in both groups (100% midwives, 90% gynecologists), although response rate was higher in midwife group (86% vs. 59%).
Borm and Mannaerts, 2000 #58070 | Geographical location: Multiple sites in 10 countries: Belgium, Denmark, France, Germany, Greece, the Netherlands, Norway, Spain, Sweden, UK Study dates: NR Size of population (no. of patients): 730 (701 in analysis) Number of cycles analyzed: 701 Number of cycles per patient: 1.0 Study type: RCT Interventions: Ganirelix or buserelin for downregulation | Age: Mean (SD): Ganirelix: 31.9 (3.6) Buserelin: 31.9 (3.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 16% Male factor: 40% Tubal factor: 29% Inclusion criteria:; - Age 18–39; - BMI 18–29; - Regular menstrual cycle 25–35 days; - Scheduled for IVF; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | 1) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Borm and Mannaerts, 2000 #58070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Borm and Mannaerts, 2000 #58070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Ganirelix | 94 | 369 | 463 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Borm and Mannaerts, 2000 #58070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Buserelin | 61 | 177 | 238 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Borm and Mannaerts, 2000 #58070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Total | 155 | 546 | 701 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Borm and Mannaerts, 2000 #58070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Borm and Mannaerts, 2000 #58070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 0.79 | 0.60 | 1.05 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Borm and Mannaerts, 2000 #58070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | 2) OHSS: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Borm and Mannaerts, 2000 #58070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | OHSS + | OHSS - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Borm and Mannaerts, 2000 #58070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Ganirelix | 11 | 452 | 463 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Borm and Mannaerts, 2000 #58070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Buserelin | 14 | 224 | 238 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Borm and Mannaerts, 2000 #58070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Total | 25 | 676 | 701 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Borm and Mannaerts, 2000 #58070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Rel risk | 0.40 | 0.19 | 0.88
Branigan, Estes, Walker, et al., 2006 #50730 | Geographical location: Bellingham, WA Study dates: NR Size of population (no. of patients): 64 (94 randomized but 31 dropped after randomization and not analyzed.) Number of cycles analyzed: NR Number of cycles per patient: Cannot be calculated Study type: RCT Interventions: Group 1: Thorough sonographic oocyte retrieval (SER) Group 2: Routine SER | Age: Mean (SD): 30 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 64 (100%) Inclusion criteria: Amenorrheic or severely oligomenorrheic, hyperandrogenism either clinical (hirsutism, acne) and/or biochemical (elevated testosterone level, >1.0 ng/mL), unresponsive to clomophene in any dose either with or without adjuvant therapy (oral contraceptives, metformin, dexamethasone), longstanding infertility of > 18 mo and absence of other infertility factors other than anovulation, absence of other androgen excess or ovulation disorders, planning to undergo IVF, did not conceive during the IVF cycle (note that patients who did conceive during IVF cycle were randomized but dropped and not analyzed) Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: serum HCG elevation and 7-week gestational ultrasound scans Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: - Adequacy of randomization concealment: -
Branigan, Estes, Walker, et al., 2006 #50730 | | | Definition(s) of outcome(s): Pregnancy: serum HCG elevation and 7-week gestational ultrasound scans Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: - Adequacy of randomization concealment: -
Branigan, Estes, Walker, et al., 2006 #50730 | | | Definition(s) of outcome(s): Pregnancy: serum HCG elevation and 7-week gestational ultrasound scans Live birth: NR Multiples: NR Complications: NR | Thorough SER | 8 | 26 | 34 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: - Adequacy of randomization concealment: -
Branigan, Estes, Walker, et al., 2006 #50730 | | | Definition(s) of outcome(s): Pregnancy: serum HCG elevation and 7-week gestational ultrasound scans Live birth: NR Multiples: NR Complications: NR | Routine SER | 0 | 30 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: - Adequacy of randomization concealment: -
Branigan, Estes, Walker, et al., 2006 #50730 | | | Definition(s) of outcome(s): Pregnancy: serum HCG elevation and 7-week gestational ultrasound scans Live birth: NR Multiples: NR Complications: NR | Total | 8 | 56 | 64 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: - Adequacy of randomization concealment: -
Branigan, Estes, Walker, et al., 2006 #50730 | | | Definition(s) of outcome(s): Pregnancy: serum HCG elevation and 7-week gestational ultrasound scans Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: - Adequacy of randomization concealment: -
Rel risk | 15.06 | 0.91 | 250.34
Brook, Khalaf, Coomarasamy, et al., 2006 #50750 | Geographical location: London, UK Study dates: Apr 2004–Mar 2005 Size of population (no. of patients): 350 Number of cycles analyzed: 350 Number of cycles per patient: 1.0 Study type: RCT Interventions: Treatment arm: 750 mg co-amoxiclav tablets night before embryo transfer (day 2, 3, or 4), 750 mg 2 hours prior to transfer Control: No tablets (no placebo used) | Age (mean [SD]): Treatment: 34.7 (4.1) Control: 34.4 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 26.3% Endometriosis: 3.4% Male factor: 51.4% Tubal factor: 9.1% PCOS: 1.1% Other (PGD): 6.3% Inclusion criteria: Scheduled to undergo transvaginal oocyte retrieval and embryo transfer Exclusion criteria: Contraindications to antibiotics; not planning on embryo transfer; required antibiotics based on history of prior infection or high risk | Definition(s) of outcome(s): Pregnancy: Gestational sac with positive FHR Live birth: NR Multiples: NR Complications: NR Other: Catheter transfer tips cultured for bacteria, difference in contamination rates | 1) Clinical pregnancy: | | | | Comments: Excellent reporting of study details Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Brook, Khalaf, Coomarasamy, et al., 2006 #50750 | | | | | Preg + | Preg - | | Comments: Excellent reporting of study details Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Brook, Khalaf, Coomarasamy, et al., 2006 #50750 | | | | Co-amoxiclav | 64 | 114 | 178 | Comments: Excellent reporting of study details Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Brook, Khalaf, Coomarasamy, et al., 2006 #50750 | | | | Control | 61 | 111 | 172 | Comments: Excellent reporting of study details Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Brook, Khalaf, Coomarasamy, et al., 2006 #50750 | | | | | 125 | 225 | 350 | Comments: Excellent reporting of study details Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Brook, Khalaf, Coomarasamy, et al., 2006 #50750 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: Excellent reporting of study details Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Brook, Khalaf, Coomarasamy, et al., 2006 #50750 | | | | Rel risk | 1.01 | 0.77 | 1.34 | Comments: Excellent reporting of study details Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Brook, Khalaf, Coomarasamy, et al., 2006 #50750 | | | | 2) Bacterial contamination: | | | | Comments: Excellent reporting of study details Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Brook, Khalaf, Coomarasamy, et al., 2006 #50750 | | | | | Culture + | Culture - | | Comments: Excellent reporting of study details Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Brook, Khalaf, Coomarasamy, et al., 2006 #50750 | | | | Co-amoxiclav | 76 | 78 | 154 | Comments: Excellent reporting of study details Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Brook, Khalaf, Coomarasamy, et al., 2006 #50750 | | | | Control | 81 | 49 | 130 | Comments: Excellent reporting of study details Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Brook, Khalaf, Coomarasamy, et al., 2006 #50750 | | | | | 157 | 127 | 284 | Comments: Excellent reporting of study details Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Brook, Khalaf, Coomarasamy, et al., 2006 #50750 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: Excellent reporting of study details Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Brook, Khalaf, Coomarasamy, et al., 2006 #50750 | | | | Rel risk | 0.79 | 0.64 | 0.98 | Comments: Excellent reporting of study details Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
3) Pregnancy rates significantly lower with positive cultures in logistic regression
Bungum, Bungum, Humaidan, et al., 2003 #15740 | Geographical location: Skive, Denmark Study dates: Dec 2001 – May 2002 Size of population: 118 Day 3 ET: 57 Day 5 ET: 61 Number of cycles analyzed: 118 Number of cycles per patient: 1.0 Study type: RCT Interventions: Pts undergoing IVF/ICSI randomized to Day 3 vs. Day 5 ET. All pts in Day 3 grp had 2 embryos transferred, whereas 2 pts in Day 5 group only had one embryo transferred. | Age: Mean: Day 3 ET Grp: 31.3 Day 5 ET Grp: 31.2 Range: Day 3 ET Grp: 22.0–39.0 Day 5 ET Grp: 22.5–39.3 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Note: Day 3 ICSI cycles 51%, day 5 64% Inclusion criteria:; - 3 or more 8-cell embryos on Day 3 with < 20% fragmentation; - Age < 40; - BMI < 30; - FSH < 12; - Received standard luteal phase down regulation with rFSH treatment; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy:; - Biochemical: + hCG; - Clinical: USD with + FCM; Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments:; - Low power of 0.32 for clinical pregnancy; - % of pts receiving ICSI was higher in Day 5 grp; - Diagnoses NR; Quality assessment: Randomization method: NR Blinding: NR Dropout rate < 20%: NR Adequacy of randomization concealment: NR
Bungum, Bungum, Humaidan, et al., 2003 #15740 | | | Definition(s) of outcome(s): Pregnancy:; - Biochemical: + hCG; - Clinical: USD with + FCM; Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Bungum, Bungum, Humaidan, et al., 2003 #15740 | | | Definition(s) of outcome(s): Pregnancy:; - Biochemical: + hCG; - Clinical: USD with + FCM; Live birth: NR Multiples: NR Complications: NR | Day 5 | 32 | 29 | 61
Bungum, Bungum, Humaidan, et al., 2003 #15740 | | | Definition(s) of outcome(s): Pregnancy:; - Biochemical: + hCG; - Clinical: USD with + FCM; Live birth: NR Multiples: NR Complications: NR | Day 3 | 36 | 21 | 57
Bungum, Bungum, Humaidan, et al., 2003 #15740 | | | Definition(s) of outcome(s): Pregnancy:; - Biochemical: + hCG; - Clinical: USD with + FCM; Live birth: NR Multiples: NR Complications: NR | | 68 | 50 | 118
Bungum, Bungum, Humaidan, et al., 2003 #15740 | | | Definition(s) of outcome(s): Pregnancy:; - Biochemical: + hCG; - Clinical: USD with + FCM; Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Bungum, Bungum, Humaidan, et al., 2003 #15740 | | | Definition(s) of outcome(s): Pregnancy:; - Biochemical: + hCG; - Clinical: USD with + FCM; Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.83 | 0.61 | 1.13
2) A statistically greater number of patients had embryos frozen on Day 3 vs. Day 5.
Cerne, Bergh, Borg, et al., 2006 #50920 | Geographical location: Goteborg and Stockholm, Sweden Study dates: Oct 2004 to Jan 2005 Size of population (no. of patients): 183 Number of cycles analyzed: 183 Number of cycles per patient: 1.0 Study type: RCT Interventions: Preovarian block (POB) Paracervical block (PCB) | Age: Mean (SD): POB: 34.5 (3.9) PCB: 34.3 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Swedish speaking Exclusion criteria: Participated previously in this study, lidocaine allergy, only one ovary or abnormal position of ovaries (i.e. reachable only when passing the aspiration needle through uterus) and coasting more than 1 day because of high risk of ovarian hyperstimulation syndrome. | Definition(s) of outcome(s): Pregnancy: Biochemical pregnancy: positive urinary HCG test 14 days after embryo transfer Clinical pregnancy: ultrasound verification of fetal heartbeat at least 5 weeks after embryo transfer. Live birth: NR Multiples: NR Complications: Pain, adverse effects | 1) Biochemical pregnancy: | | | | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Cerne, Bergh, Borg, et al., 2006 #50920 | | | | | Biochem preg + | Biochem preg - | Total | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Cerne, Bergh, Borg, et al., 2006 #50920 | | | | POB | 28 | 68 | 96 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Cerne, Bergh, Borg, et al., 2006 #50920 | | | | PCB | 30 | 57 | 87 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Cerne, Bergh, Borg, et al., 2006 #50920 | | | | Total | 58 | 125 | 183 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Cerne, Bergh, Borg, et al., 2006 #50920 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Cerne, Bergh, Borg, et al., 2006 #50920 | | | | Rel risk | 0.85 | 0.55 | 1.29 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Cerne, Bergh, Borg, et al., 2006 #50920 | | | | 2) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Cerne, Bergh, Borg, et al., 2006 #50920 | | | | | Clinical preg + | Clinical preg - | Total | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Cerne, Bergh, Borg, et al., 2006 #50920 | | | | POB | 23 | 68 | 91 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Cerne, Bergh, Borg, et al., 2006 #50920 | | | | PCB | 24 | 63 | 87 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Cerne, Bergh, Borg, et al., 2006 #50920 | | | | Total | 47 | 131 | 178 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Cerne, Bergh, Borg, et al., 2006 #50920 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Cerne, Bergh, Borg, et al., 2006 #50920 | | | | Rel risk | 0.92 | 0.56 | 1.50 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Cerne, Bergh, Borg, et al., 2006 #50920 | | | | 3) No difference in pain scores | | | | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
4) No adverse effects
Cha and Wirth, 2001 #10 | Geographical location: Seoul, South Korea Study dates: Dec 1998–March 1999 Size of population (no. of patients): 199 Number of cycles analyzed: 199 (30 not analyzed due to cancellation) Number of cycles per patient: 1.00 Study type: RCT Interventions:; - COH with GnRH agonist/gonadotropins (not specified); - Intervention: Intercessory prayer (individuals praying for either general benefit or specific outcome—conception—in other individual) vs no intercessory prayer | Age: Mean (SD): 33.9 (4.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 26–46; - Candidates for IVF; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | 1) Pregnancy - intention to treat: | | | | Comments:; - No informed consent; - Complex intervention allocation of both directed and non-directed prayer—ultimate allocations not reported; Quality assessment: Randomization method: - Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Cha and Wirth, 2001 #10 | | Age: Mean (SD): 33.9 (4.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 26–46; - Candidates for IVF; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg -
Cha and Wirth, 2001 #10 | | Age: Mean (SD): 33.9 (4.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 26–46; - Candidates for IVF; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | Prayer | 44 | 56 | 100
Cha and Wirth, 2001 #10 | | Age: Mean (SD): 33.9 (4.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 26–46; - Candidates for IVF; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | No Prayer | 21 | 78 | 99
Cha and Wirth, 2001 #10 | | Age: Mean (SD): 33.9 (4.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 26–46; - Candidates for IVF; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | | 65 | 134 | 199
Cha and Wirth, 2001 #10 | | Age: Mean (SD): 33.9 (4.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 26–46; - Candidates for IVF; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Cha and Wirth, 2001 #10 | | Age: Mean (SD): 33.9 (4.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 26–46; - Candidates for IVF; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | Rel risk | 2.07 | 1.34 | 3.22
2) Higher multiple pregnancy rate in prayer group
Chakravarty, Shirazee, Dam, et al., 2005 #39460 | Geographical location: West Bengal, India Study dates: Jan 2002 – June 2003 Size of population: Grp 1: 351 vaginal micronized progesterone Grp 2: 79 oral dydrogesterone Number of cycles analyzed: 430 Number of cycles per patient: 1.0 Study type: RCT Interventions: IVF/ICSI cycles randomized to vaginal micronized progesterone vs. oral dydrogesterone | Age: Range: 25–42 Age distribution given and same for each group Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1:; - Unexplained infertility: 67 [19.1]; - Endometriosis: 34 [9.7]; - Male factor: 135 [38.7]; - Tubal factor: 114 [32.5]; - PCOS: 0; - Other (specify): 0; Grp 2:; - Unexplained infertility: 12 [15.2]; - Endometriosis: 12 [15.2]; - Male factor: 21 [26.6]; - Tubal factor: 34 [43]; - PCOS: 0; - Other (specify): 0; Inclusion criteria: IVF or ICSI with endometrial thickness of 7–12mm and no endometrial pathology Exclusion criteria:; - Previous failed IVF/ICSI; - PCOS; - Advanced endometriosis; - Dense pelvic adhesions; - Genital TB | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | 1) Live birth: | | | | Comments:; - Intentional 5:1 randomization; - Low numbers in oral group; Quality assessment: Randomization method: NR Blinding: NR Dropout rate < 20%: + Adequacy of randomization concealment: NR
Chakravarty, Shirazee, Dam, et al., 2005 #39460 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments:; - Intentional 5:1 randomization; - Low numbers in oral group; Quality assessment: Randomization method: NR Blinding: NR Dropout rate < 20%: + Adequacy of randomization concealment: NR
Chakravarty, Shirazee, Dam, et al., 2005 #39460 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | Study drug | 19 | 60 | 79 | Comments:; - Intentional 5:1 randomization; - Low numbers in oral group; Quality assessment: Randomization method: NR Blinding: NR Dropout rate < 20%: + Adequacy of randomization concealment: NR
Chakravarty, Shirazee, Dam, et al., 2005 #39460 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | Control | 80 | 271 | 351 | Comments:; - Intentional 5:1 randomization; - Low numbers in oral group; Quality assessment: Randomization method: NR Blinding: NR Dropout rate < 20%: + Adequacy of randomization concealment: NR
Chakravarty, Shirazee, Dam, et al., 2005 #39460 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | | 99 | 331 | 430 | Comments:; - Intentional 5:1 randomization; - Low numbers in oral group; Quality assessment: Randomization method: NR Blinding: NR Dropout rate < 20%: + Adequacy of randomization concealment: NR
Chakravarty, Shirazee, Dam, et al., 2005 #39460 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments:; - Intentional 5:1 randomization; - Low numbers in oral group; Quality assessment: Randomization method: NR Blinding: NR Dropout rate < 20%: + Adequacy of randomization concealment: NR
Rel risk | 1.06 | 0.68 | 1.63
Chan, Ng, Chan, et al., 2006 #50950 | Geographical location: Hong Kong, China Study dates: Feb 2001–June 2003 Size of population (no. of patients): 22 Number of cycles analyzed: 227 (184 analyzed due to withdrawals after randomization) Number of cycles per patient: 1.00 Study type: RCT Interventions:; - All subjects underwent IVF with COH (GnRH agonist and hMG); - Randomized to no intervention or Eastern Body-Mind-Spirit (EBMS) counseling sessions, focusing on; 1 mini-lectures on Traditional Chinese Medicine, which views health as a state of mind-body harmony;; 2 stress-reduction training coupled with tai-chi exercises, meditation, and breathing techniques;; 3 activities, such as singing, journal writing, and drawing, to encourage the discovery of positive meaning from negative experiences; and; 4 reading materials excerpted from ancient Chinese philosophical writings on suffering and the meaning of life.; 4 weekly sessions of 3 hours each, done prior to initiation of first IVF cycle | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy (intention-to-treat): | | | | Comments:; - More male factor, more single embryo transfers in control group; - Drop-out rate higher in intervention group; - 2 spontaneous pregnancies in intervention; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Chan, Ng, Chan, et al., 2006 #50950 | | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Chan, Ng, Chan, et al., 2006 #50950 | | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | EBMS | 20 | 81 | 101
Chan, Ng, Chan, et al., 2006 #50950 | | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | Control | 16 | 110 | 126
Chan, Ng, Chan, et al., 2006 #50950 | | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | | 36 | 191 | 227
Chan, Ng, Chan, et al., 2006 #50950 | | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Chan, Ng, Chan, et al., 2006 #50950 | | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.56 | 0.85 | 2.85
Chan, Ng, Chan, et al., 2006 #50950 | | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy (intention-to-treat):
Chan, Ng, Chan, et al., 2006 #50950 | | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Chan, Ng, Chan, et al., 2006 #50950 | | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | EBMS | 13 | 88 | 101
Chan, Ng, Chan, et al., 2006 #50950 | | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | Control | 13 | 113 | 126
Chan, Ng, Chan, et al., 2006 #50950 | | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | | 26 | 201 | 227
Chan, Ng, Chan, et al., 2006 #50950 | | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Chan, Ng, Chan, et al., 2006 #50950 | | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.25 | 0.61 | 2.57
Chan, Ng, Chan, et al., 2006 #50950 | | Age: Mean (SD): EBMS: 36.0 (3.3) Control: 35.0 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire randomized population Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Main outcome: State-Trait Anxiety Scale score Pregnancy: Presence of gestational sac or Live birth: NR Multiples: NR Complications: NR | Study drug | 13 | 88 | 101
3) Significant reduction in state anxiety, but not trait anxiety, in intervention group analyzed
Chang, Kenley, Burns, et al., 2001 #58080 | Geographical location: 20 centers in U.S. in Alabama, California, Florida, Illinois, Maryland, Massachusetts, Missouri, New Jersey, North Carolina, Pennsylvania, Rhode Island, South Carolina Study dates: NR Size of population (no. of patients): 275 Number of cycles analyzed: 275 Number of cycles per patient: 1.0 Study type: RCT Interventions: Long protocol GnRH, uFSH stimulation, randomized to; (a) 250 μg rhCG; (b) 500 μg rhCG; (c) 10000 IU uhCG | Age: Mean (SD): 250 rhCG: 32.6 (3.7) 500 rhCG: 31.7 (3.5) uhCG: 32.2 (3.7) Race/ethnicity (n [%]): White: 80% African-American: 7% Hispanic: 6% Other: 7% Diagnoses (n [%]): Unexplained infertility: Endometriosis: 22% Male factor: 18% Tubal factor: 60% Inclusion criteria:; - Age 18 to 38; - Both ovaries present; - Regular menstrual cycles of 25–35 days; - Either ≥ 2-year history of infertility or had tubal disease; - Non-obese (BMI < 30 kg/m^2^); - No more than one previous ART attempt; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | 1) Pregnancy, 250 ug rhCG vs uhCG: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | 250 ug rhCG | 33 | 61 | 94 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | uhCG | 33 | 59 | 92 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Total | 66 | 120 | 186 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.98 | 0.66 | 1.44 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | 2) Pregnancy, 500 ug rhCG vs uhCG: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | 500 ug rhCG | 32 | 57 | 89 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | uhCG | 33 | 59 | 92 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Total | 65 | 116 | 181 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.00 | 0.68 | 1.48 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | 3) Live birth, 250 ug rhCG vs uhCG: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Birth + | Birth - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | 250 ug rhCG | 29 | 65 | 94 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | uhCG | 28 | 64 | 92 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Total | 57 | 129 | 186 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.01 | 0.66 | 1.56 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | 4) Live birth, 500 ug rhCG vs uhCG: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Birth + | Birth - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | 500 ug rhCG | 27 | 62 | 89 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | uhCG | 28 | 64 | 92 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Total | 55 | 126 | 181 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Chang, Kenley, Burns, et al., 2001 #58080 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.00 | 0.64 | 1.55
Check, Check, Choel, et al., 2004 #9470 | Geographical location: NR Study dates: NR Size of population (no. of patients): 60 randomized Number of cycles analyzed: 69 (or 76) Number of cycles per patient: 1.15 (or 1.27) Study type: RCT Interventions: Agonist: SQ 0.5 mg/d leuprolide for 10 days from mid-leuteal phase, then 0.25 mg once gonatotropins were started (300 IU in divided doses ) IM or SC after suppression was observed Antagonist: 250 μgm of ganirelix beginning with observation of at least one dominant follicle with diameter >= 14 mm in conjunction with a serum estradiol E2 level >= 1000 pg/mL. Gonadotropin 300 IU in divided doses beginning day 3 of cycle. In both groups, the gonadotropins included 300 IU of follitropin beta or 150 follitropin beta and 150 hMG, depending on financial situation. | Age: Mean: 36 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples requiring IVF or intracytoplasmic sperm injection Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - (none) Dropout rate < 20%: - (14/60 [23%] couples not clearly accounted for) Adequacy of randomization concealment: - (open label)
Check, Check, Choel, et al., 2004 #9470 | | Age: Mean: 36 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples requiring IVF or intracytoplasmic sperm injection Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Clinical Preg + | Clinical Preg -
Check, Check, Choel, et al., 2004 #9470 | | Age: Mean: 36 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples requiring IVF or intracytoplasmic sperm injection Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Antagonist | 6 | 13 | 19
Check, Check, Choel, et al., 2004 #9470 | | Age: Mean: 36 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples requiring IVF or intracytoplasmic sperm injection Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Agonist | 12 | 16 | 28
Check, Check, Choel, et al., 2004 #9470 | | Age: Mean: 36 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples requiring IVF or intracytoplasmic sperm injection Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 18 | 29 | 47
Check, Check, Choel, et al., 2004 #9470 | | Age: Mean: 36 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples requiring IVF or intracytoplasmic sperm injection Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Check, Check, Choel, et al., 2004 #9470 | | Age: Mean: 36 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples requiring IVF or intracytoplasmic sperm injection Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.74 | 0.34 | 1.62
Check, Check, Choel, et al., 2004 #9470 | | Age: Mean: 36 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples requiring IVF or intracytoplasmic sperm injection Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 2) Viable pregnancy:
Check, Check, Choel, et al., 2004 #9470 | | Age: Mean: 36 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples requiring IVF or intracytoplasmic sperm injection Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Viable Preg + | Viable Preg -
Check, Check, Choel, et al., 2004 #9470 | | Age: Mean: 36 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples requiring IVF or intracytoplasmic sperm injection Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Antagonist | 6 | 13 | 19
Check, Check, Choel, et al., 2004 #9470 | | Age: Mean: 36 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples requiring IVF or intracytoplasmic sperm injection Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Agonist | 9 | 19 | 28
Check, Check, Choel, et al., 2004 #9470 | | Age: Mean: 36 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples requiring IVF or intracytoplasmic sperm injection Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 15 | 32 | 47
Check, Check, Choel, et al., 2004 #9470 | | Age: Mean: 36 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples requiring IVF or intracytoplasmic sperm injection Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 0.98 | 0.42 | 2.31
Chen and Kattera, 2006 #51040 | Geographical location: Singapore Study dates: June 2002–June 2004 Size of population (no. of patients): 330 Number of cycles analyzed: 330 Number of cycles per patient: 1.0 Study type: RCT Interventions: Embryo selection for transfer randomized to; (a) day 3 morphology + progression + Day 1 pronuclear morphology; (A nucleoli large or medium in size and aligned between the two pronuclei (polarized);; B nucleoli llarge or medium and without any particular alignment;; C nucleoli were small or pinpoint with any type of nucleolar alignment.); (b) day 3 morphology and progession + day 1 early zygote cleavage status (A: 2 cells at 26 h; B: PN breakdown had occurred but cleavage had not occurred. C: PN were still intact. | Age: Mean (SD): Morphology 35.7 (3.7), cleavage 35.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria:; - Azoospermia; - Poor response to COH; - Mixed classification of embryos transferred | Definition(s) of outcome(s): Pregnancy: + hCG with rising titer Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy (all randomized subjects): | | | | Comments: Denominators for reported rates unclear Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Chen and Kattera, 2006 #51040 | | | Definition(s) of outcome(s): Pregnancy: + hCG with rising titer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: Denominators for reported rates unclear Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Chen and Kattera, 2006 #51040 | | | Definition(s) of outcome(s): Pregnancy: + hCG with rising titer Live birth: NR Multiples: NR Complications: NR | Cleavage | 41 | 124 | 165 | Comments: Denominators for reported rates unclear Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Chen and Kattera, 2006 #51040 | | | Definition(s) of outcome(s): Pregnancy: + hCG with rising titer Live birth: NR Multiples: NR Complications: NR | Morphology | 47 | 118 | 165 | Comments: Denominators for reported rates unclear Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Chen and Kattera, 2006 #51040 | | | Definition(s) of outcome(s): Pregnancy: + hCG with rising titer Live birth: NR Multiples: NR Complications: NR | | 88 | 242 | 330 | Comments: Denominators for reported rates unclear Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Chen and Kattera, 2006 #51040 | | | Definition(s) of outcome(s): Pregnancy: + hCG with rising titer Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Denominators for reported rates unclear Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Chen and Kattera, 2006 #51040 | | | Definition(s) of outcome(s): Pregnancy: + hCG with rising titer Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.87 | 0.61 | 1.25 | Comments: Denominators for reported rates unclear Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Similar results when divided by score
Cheung, Lam, Lok, et al., 2005 #9190 | Geographical location: Hong Kong, China Study dates: Apr 2001 – Dec 2003 Size of population: 66; - GnRH antagonist: 31 (2 dropouts); - GnRH agonist: 32 (1 dropout); Number of cycles analyzed: 66 Number of cycles per patient: 1.00 Study type: RCT Interventions: Compares women undergoing IVF/ICSI treated with GnRH antagonist starting on day 6 and a GnRH agonist started in the luteal phase | Age: Mean (SD): Antagonist grp: 36.0 (2.6) Agonist grp: 36.3 (3.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Antagonist group:; - Unexplained infertility: 3 (9.7%); - Endometriosis: 6 (19.4%); - Male factor: 4 (12.9%); - Tubal factor: 18 (58.0%); Agonist group:; - Unexplained infertility: 7 (21.9%); - Endometriosis: 6 (18.8%); - Male factor: 5 (15.6%); - Tubal factor: 13 (40.6%); - Other (specify): 1 (3.1%); Inclusion criteria:; - History of poor ovarian response with history of < 3 mature follicles with previous IVF using luteal agonist, or pts with basal FSH > 10; Exclusion criteria: PCOS | Definition(s) of outcome(s): Pregnancy: Clinical - defined as sac on USD Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy rate: | | | | Comments:; - Number of embryos transferred statistically greater in antagonist group; - Sample size based on expected number of oocytes; - Low power; - Not intent-to-treat analysis; Quality assessment: Randomization method: + (computer-generated random numbers) Blinding: - (investigators blinded, not subjects) Dropout rate < 20%: + Adequacy of randomization concealment: +
Cheung, Lam, Lok, et al., 2005 #9190 | | | Definition(s) of outcome(s): Pregnancy: Clinical - defined as sac on USD Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total
Cheung, Lam, Lok, et al., 2005 #9190 | | | Definition(s) of outcome(s): Pregnancy: Clinical - defined as sac on USD Live birth: NR Multiples: NR Complications: NR | Antag + | 5 | 26 | 31
Cheung, Lam, Lok, et al., 2005 #9190 | | | Definition(s) of outcome(s): Pregnancy: Clinical - defined as sac on USD Live birth: NR Multiples: NR Complications: NR | Agon - | 3 | 29 | 32
Cheung, Lam, Lok, et al., 2005 #9190 | | | Definition(s) of outcome(s): Pregnancy: Clinical - defined as sac on USD Live birth: NR Multiples: NR Complications: NR | Total | 8 | 55 | 63
Cheung, Lam, Lok, et al., 2005 #9190 | | | Definition(s) of outcome(s): Pregnancy: Clinical - defined as sac on USD Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.72 | 0.45 | 6.59
Coroleu, Barri, Carreras, et al., 2002 #790 | Geographical location: Barcelona, Spain Study dates: NR Size of population: 184; - USD grp: 93; - Touch grp: 91; Number of cycles analyzed: 184 Number of cycles per patient: 1.00 Study type: RCT Interventions: In women undergoing frozen embryo transfer, compares ultrasound-guided transfer vs. clinical touch transfer | Age: Mean (SD): USD grp: 36.6 (3.4) Touch grp: 36.2 (3.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Previous IVF with both luteal down-regulation or flare cycles; - Had frozen embryos for transfer; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | 1) Clinical pregnancy rate: | | | | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | USD | 32 | 61 | 93 | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | Touch | 18 | 73 | 91 | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | Total | 50 | 134 | 184 | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | Rel risk | 1.74 | 1.06 | 2.87 | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | 2) SAB rate: | | | | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | | SAB + | SAB - | Total | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | USD | 7 | 25 | 32 | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | Touch | 4 | 14 | 18 | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | Total | 11 | 39 | 50 | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | Rel risk | 0.98 | 0.33 | 2.91 | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | 3) Multiple rate: | | | | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | | Mult + | Mult - | Total | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | USD | 6 | 26 | 32 | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | Touch | 6 | 12 | 18 | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | Total | 12 | 38 | 50 | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Barri, Carreras, et al., 2002 #790 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: Yes Complications: SAB rate | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + (computer-generated table) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.56 | 0.21 | 1.49
Coroleu, Barri, Carreras, et al., 2006 #51260 | Geographical location: Barcelona, Spain Study dates: Sep 2004–Jan 2005 Size of population (no. of patients): 193 Number of cycles analyzed: 193 Number of cycles per patient: 1.00 Study type: RCT Interventions: Soft Wallace catheter (standard) or echogenic catheter (SureView) | Age: Mean (SD): Echogenic catheter: 35.9 (2.8); standard 35.5 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 32 (16.3%) Endometriosis: 28 (14.5%) Male factor: 70 (36.2%) Tubal factor: 43 (22.2%) Inclusion criteria: Age 25–43, scheduled for IVF/ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac at 6 weeks Live birth: NR Multiples: Yes Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Coroleu, Barri, Carreras, et al., 2006 #51260 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 6 weeks Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Coroleu, Barri, Carreras, et al., 2006 #51260 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 6 weeks Live birth: NR Multiples: Yes Complications: NR | Echogenic | 53 | 45 | 98 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Coroleu, Barri, Carreras, et al., 2006 #51260 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 6 weeks Live birth: NR Multiples: Yes Complications: NR | Standard | 39 | 56 | 95 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Coroleu, Barri, Carreras, et al., 2006 #51260 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 6 weeks Live birth: NR Multiples: Yes Complications: NR | | 92 | 101 | 193 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Coroleu, Barri, Carreras, et al., 2006 #51260 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 6 weeks Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Coroleu, Barri, Carreras, et al., 2006 #51260 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 6 weeks Live birth: NR Multiples: Yes Complications: NR | Rel risk | 1.32 | 0.97 | 1.78 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Coroleu, Barri, Carreras, et al., 2006 #51260 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 6 weeks Live birth: NR Multiples: Yes Complications: NR | 2) Twin (compared to singletons) among pregnancies: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Coroleu, Barri, Carreras, et al., 2006 #51260 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 6 weeks Live birth: NR Multiples: Yes Complications: NR | | Twins | Single-ton | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Coroleu, Barri, Carreras, et al., 2006 #51260 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 6 weeks Live birth: NR Multiples: Yes Complications: NR | Echogenic | 17 | 36 | 53 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Coroleu, Barri, Carreras, et al., 2006 #51260 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 6 weeks Live birth: NR Multiples: Yes Complications: NR | Standard | 3 | 36 | 39 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Coroleu, Barri, Carreras, et al., 2006 #51260 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 6 weeks Live birth: NR Multiples: Yes Complications: NR | | 20 | 72 | 92 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Coroleu, Barri, Carreras, et al., 2006 #51260 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 6 weeks Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Coroleu, Barri, Carreras, et al., 2006 #51260 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 6 weeks Live birth: NR Multiples: Yes Complications: NR | Rel risk | 4.17 | 1.31 | 13.24 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
3) Mean transfer time significantly shorter with echogenic catheter (42.6 seconds vs. 60.2 seconds).
Coroleu, Carreras, Veiga, et al., 2000 #8550 | Geographical location: Barcelona, Spain Study dates: Oct 1998–Jan 1999 Size of population (no. of patients): 362 Number of cycles analyzed: 362 Number of cycles per patient: 1.0 Study type: RCT Interventions: All interventions similar until embryo transfer U/S group: Catheter visualized, embryos released when tip within 1.5 cm of fundus, confirmation that embryos expelled Clinical touch: Embryos transferred based on clinician's judgment - as close as possible to fundus without touching | Age (mean [SD]): Ultrasound: 34.6 (4.0) Clinical touch: 34.5 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 33 (9.1%) Endometriosis: 23 (6.4%) Male factor: 131(36.2%) Tubal factor: 99 (27.3%) Multiple diagnoses: 76 (21.0%) Distributions similar between arms Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6–8 weeks of amenorrhea (not stated if FHR required) Ongoing pregnancy: Viable pregnancy at 12–16 weeks Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: Randomization method NR Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Carreras, Veiga, et al., 2000 #8550 | | | | | Preg + | Preg - | | Comments: Randomization method NR Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Carreras, Veiga, et al., 2000 #8550 | | | | U/S guidance | 91 | 91 | 182 | Comments: Randomization method NR Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Carreras, Veiga, et al., 2000 #8550 | | | | Clinical touch | 61 | 119 | 180 | Comments: Randomization method NR Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Carreras, Veiga, et al., 2000 #8550 | | | | | 152 | 210 | 362 | Comments: Randomization method NR Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Carreras, Veiga, et al., 2000 #8550 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: Randomization method NR Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Carreras, Veiga, et al., 2000 #8550 | | | | Rel risk | 1.48 | 1.15 | 1.90 | Comments: Randomization method NR Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Carreras, Veiga, et al., 2000 #8550 | | | | 2) Ongoing pregnancy: | | | | Comments: Randomization method NR Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Carreras, Veiga, et al., 2000 #8550 | | | | | Preg + | Preg - | | Comments: Randomization method NR Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Carreras, Veiga, et al., 2000 #8550 | | | | U/S guidance | 85 | 97 | 182 | Comments: Randomization method NR Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Carreras, Veiga, et al., 2000 #8550 | | | | Clinical touch | 52 | 128 | 180 | Comments: Randomization method NR Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Carreras, Veiga, et al., 2000 #8550 | | | | | 137 | 225 | 362 | Comments: Randomization method NR Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Carreras, Veiga, et al., 2000 #8550 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: Randomization method NR Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Coroleu, Carreras, Veiga, et al., 2000 #8550 | | | | Rel risk | 1.62 | 1.23 | 2.13 | Comments: Randomization method NR Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
3) In subgroup analysis, no difference in outcomes with single embryo transfer, but numbers small (n = 13 in U/S group, n = 15 in clinical touch group).
Dal Prato, Borini, Cattoli, et al., 2002 #1990 | Geographical location: Bologna, Italy Study dates: Apr 1999 – Sep Size of population (no. of patients): 296 Number of cycles analyzed: 296 Number of cycles per patient: 1 Study type: RCT Interventions: GnRH agonist: Single IM injection of depot GnRH administered in the mid-luteal phase of the cycle. At the onset of menses, 17β-estradiol transdermal patches applied at increasing doses for at least 12 days, from 100 μgm to 300μgm. No GnRH agonist: On day 1 of menstrual cycle 200μgm 17 β-estradiol transdermal, increased to 300μgm after 7 days. | Age: Mean (SD): 34.25 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women with normal ovarian function for frozen-thawed embryo transfer. Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Presence of one or more gestational sacs on ultrasonography, performed at least 4 weeks after embryo transfer Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - (not clear if U/S assessment of pregnancy was blinded) Dropout rate < 20%: + Adequacy of randomization concealment: +
Dal Prato, Borini, Cattoli, et al., 2002 #1990 | | Age: Mean (SD): 34.25 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women with normal ovarian function for frozen-thawed embryo transfer. Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Presence of one or more gestational sacs on ultrasonography, performed at least 4 weeks after embryo transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - (not clear if U/S assessment of pregnancy was blinded) Dropout rate < 20%: + Adequacy of randomization concealment: +
Dal Prato, Borini, Cattoli, et al., 2002 #1990 | | Age: Mean (SD): 34.25 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women with normal ovarian function for frozen-thawed embryo transfer. Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Presence of one or more gestational sacs on ultrasonography, performed at least 4 weeks after embryo transfer Live birth: NR Multiples: NR Complications: NR | GnRH agonist | 28 | 118 | 146 | Comments: None Quality assessment: Randomization method: + Blinding: - (not clear if U/S assessment of pregnancy was blinded) Dropout rate < 20%: + Adequacy of randomization concealment: +
Dal Prato, Borini, Cattoli, et al., 2002 #1990 | | Age: Mean (SD): 34.25 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women with normal ovarian function for frozen-thawed embryo transfer. Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Presence of one or more gestational sacs on ultrasonography, performed at least 4 weeks after embryo transfer Live birth: NR Multiples: NR Complications: NR | No GnRH agonist | 34 | 116 | 150 | Comments: None Quality assessment: Randomization method: + Blinding: - (not clear if U/S assessment of pregnancy was blinded) Dropout rate < 20%: + Adequacy of randomization concealment: +
Dal Prato, Borini, Cattoli, et al., 2002 #1990 | | Age: Mean (SD): 34.25 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women with normal ovarian function for frozen-thawed embryo transfer. Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Presence of one or more gestational sacs on ultrasonography, performed at least 4 weeks after embryo transfer Live birth: NR Multiples: NR Complications: NR | Total | 62 | 234 | 296 | Comments: None Quality assessment: Randomization method: + Blinding: - (not clear if U/S assessment of pregnancy was blinded) Dropout rate < 20%: + Adequacy of randomization concealment: +
Dal Prato, Borini, Cattoli, et al., 2002 #1990 | | Age: Mean (SD): 34.25 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women with normal ovarian function for frozen-thawed embryo transfer. Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Presence of one or more gestational sacs on ultrasonography, performed at least 4 weeks after embryo transfer Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - (not clear if U/S assessment of pregnancy was blinded) Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.85 | 0.54 | 1.32
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | Geographical location: Bologna, Italy Study dates: Sep 2000 – Sep 2002 Size of population: 180; - ½-dose GnRH grp: 90, 85 received ET; - Full-dose GnRH grp: 90, 79 received ET; Number of cycles analyzed: 180 Number of cycles per patient: 1 Study type: RCT Interventions: Women undergoing IVF randomized to ½ dose GnRH agonist (1.87 mg Depot triptorelin) in the luteal phase vs. full dose GnRH agonist (3.75 ng triptorelin) in luteal phase with pFSH stimulation | Age: Mean (SEM): ½ dose: 33.2 (0.29) Full dose: 33.7 (0.33) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 25–38; - First IVF attempt; Exclusion criteria:; - Active endometriosis; - Previous ovarian surgery; - FSH > 15 | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | 1) Clinical pregnancy rate per randomized patient (fresh cycles): | | | | Comments:; - Diagnoses NR; - ½-dose group had better quality embryos; - Results not reported on intent-to-treat; pregnancy rate significantly higher by intent-to-treat compared to reported analysis; Quality assessment: Randomization method: + (sequential numbering of opaque envelopes) Blinding: + (both pt and physician) Dropout rate < 20%: + Adequacy of randomization concealment: +
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | | Preg + | Preg - | Total
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | ½ dose | 33 | 57 | 90
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | Full dose | 20 | 70 | 90
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | Total | 53 | 127 | 180
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | | Value | Lower 95% CI | Upper 95% CI
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | Rel risk | 1.65 | 1.03 | 2.65
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | 2) Cumulative pregnancy rate per patient, including transfer of frozen/thawed embryos:
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | | Preg + | Preg -
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | Study group | 49 | 41 | 90
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | Control | 29 | 61 | 90
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | | 78 | 102 | 180
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | | | Lower 95% CI | Upper 95 % CI
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | Rel risk | 1.69 | 1.19 | 2.41
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | 3) SAB rate:
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | | SAB + | SAB - | Total
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | ½ dose | 2 | 31 | 33
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | Full dose | 2 | 18 | 20
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | Total | 4 | 49 | 53
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | | Value | Lower 95% CI | Upper 95% CI
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | Rel risk | 0.61 | 0.09 | 3.97
Dal Prato, Borini, Coticchio, et al., 2004 #11250 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate | 4) Statistically greater cancellation rate in full dose grp due to lack of stimulation.
5) Statistically greater number of oocytes and embryos, and lower number of days of stimulation and dose of FSH, in ½-dose grp compared to full-dose grp.
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | Geographical location: Bologna, Italy Study dates: 9/1998 – 9/1999 Size of population: 132 Depot agonist grp: 66, 63 had ET, 2 no retrieval, 1 no transfer Daily agonist grp: 66, 63 had ET, 2 no retrieval, 1 no transfer Number of cycles analyzed: 132 Number of cycles per patient: 1.00 Study type: RCT Interventions: Women undergoing IVF/ICSI, compares down-regulation with luteal depot agonist (3.75 mg depot triptorelin) vs. luteal daily agonist (triptorelin 100 ug from luteal til menses then 50 ug until hCG). Stimulation with pFSH. | Age: Mean (SD): Depot grp: 33 ± 3.6 Daily grp: 33.8 ± 3.1 Median: NR Range: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 25–38; - Tubal, male factor or unknown infertility; Exclusion criteria:; - Active endometriosis; - Previous ovarian surgery; - FSH > 15; - Previous poor response or known history of ovarian hyperstimulation | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | 1) Clinical pregnancy rate per randomized pt: | | | | Comments:; - Diagnoses not reported; - Low power for pregnancy difference; Quality assessment: Randomization method: + (sequentially numbered opaque envelopes) Blinding: + (patients and physicians) Dropout rate < 20%: + Adequacy of randomization concealment: +
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | | Preg + | Preg -
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | Daily | 22 | 44 | 66
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | Depot | 24 | 42 | 66
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | | 46 | 86 | 132
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | | | Lower 95% CI | Upper 95 % CI
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | Rel risk | 0.92 | 0.57 | 1.46
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | 2) Clinical pregnancy rate per pt with ET:
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | | Preg + | Preg - | Total
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | Depot | 24 | 39 | 63
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | Daily | 22 | 41 | 63
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | Total | 46 | 80 | 126
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | | Value | Lower 95% CI | Upper 95% CI
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | Rel risk | 1.09 | 0.69 | 1.73
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | 3) SAB rate:
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | | SAB + | SAB - | Total
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | Depot | 2 | 22 | 24
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | Daily | 2 | 20 | 22
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | Total | 4 | 42 | 46
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | | Value | Lower 95% CI | Upper 95% CI
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | Rel risk | 0.92 | 0.14 | 5.96
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | 4) Ectopic pregnancy:
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | | Ect preg + | Ect preg - | Total
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | Depot | 1 | 23 | 24
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | Daily | 0 | 22 | 22
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | Total | 1 | 45 | 46
Dal Prato, Borini, Trevisi, et al., 2001 #4910 | | | Definition(s) of outcome(s): Pregnancy: Clinical - sac on USD Live birth: NR Multiples: NR Complications: SAB rate, ectopic rate | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 2.76 | 0.12 | 64.42
Dale, Fiorentino, de Simone, et al., 2002 #620 | Geographical location: Naples, Italy Study dates: 3/1998 – 2/1999 Size of population: 407 Zygote grp: 205, 203 had ET Embryo grp: 202, 183 had ET Number of cycles analyzed: 407 Number of cycles per patient: 1.00 Study type: RCT Interventions: Women undergoing IVF/ICSI were randomized to receive zygote transfer at 2 PN stage vs. embryo transfer on day 2 or 3 | Age: Mean (SD): Zygote grp: 33.8 ± 4.5 Embryo grp: 32.7 ± 3.5 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Zygote group: Unexplained infertility: 31 (15.1%) Endometriosis: 35 (17.1%) Male factor: 97 (47.3%) Tubal factor: 20 (9.7%) Embryo grp: Unexplained infertility: 30 (14.8%) Endometriosis: 31 (15.3%) Male factor: 78 (38.6%) Tubal factor: 29 (14.4%) Inclusion criteria: First cycle of IVF/ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical - not defined Live birth: Yes Multiples: Yes Complications: NR | 1) Clinical pregnancy rate per randomized pt: | | | | Comments:; - Greater number of zygotes transferred compared to embryos; - No SAb's reported—unusual (clinical pregnancy rate=live birth); Quality assessment: Randomization method: + (computer-generated random number table) Blinding: NR Dropout rate < 20%: + Adequacy of randomization concealment: NR
Dale, Fiorentino, de Simone, et al., 2002 #620 | | | Definition(s) of outcome(s): Pregnancy: Clinical - not defined Live birth: Yes Multiples: Yes Complications: NR | | Preg + | Preg -
Dale, Fiorentino, de Simone, et al., 2002 #620 | | | Definition(s) of outcome(s): Pregnancy: Clinical - not defined Live birth: Yes Multiples: Yes Complications: NR | Zygote | 74 | 131 | 205
Dale, Fiorentino, de Simone, et al., 2002 #620 | | | Definition(s) of outcome(s): Pregnancy: Clinical - not defined Live birth: Yes Multiples: Yes Complications: NR | Embryo | 77 | 125 | 202
Dale, Fiorentino, de Simone, et al., 2002 #620 | | | Definition(s) of outcome(s): Pregnancy: Clinical - not defined Live birth: Yes Multiples: Yes Complications: NR | | 151 | 256 | 407
Dale, Fiorentino, de Simone, et al., 2002 #620 | | | Definition(s) of outcome(s): Pregnancy: Clinical - not defined Live birth: Yes Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Dale, Fiorentino, de Simone, et al., 2002 #620 | | | Definition(s) of outcome(s): Pregnancy: Clinical - not defined Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 0.95 | 0.74 | 1.22
Dale, Fiorentino, de Simone, et al., 2002 #620 | | | Definition(s) of outcome(s): Pregnancy: Clinical - not defined Live birth: Yes Multiples: Yes Complications: NR | 2) Multiple pregnancy rate:
Dale, Fiorentino, de Simone, et al., 2002 #620 | | | Definition(s) of outcome(s): Pregnancy: Clinical - not defined Live birth: Yes Multiples: Yes Complications: NR | | Multi preg + | Multi preg - | Total
Dale, Fiorentino, de Simone, et al., 2002 #620 | | | Definition(s) of outcome(s): Pregnancy: Clinical - not defined Live birth: Yes Multiples: Yes Complications: NR | Zygote | 23 | 51 | 74
Dale, Fiorentino, de Simone, et al., 2002 #620 | | | Definition(s) of outcome(s): Pregnancy: Clinical - not defined Live birth: Yes Multiples: Yes Complications: NR | Embryo | 40 | 37 | 77
Dale, Fiorentino, de Simone, et al., 2002 #620 | | | Definition(s) of outcome(s): Pregnancy: Clinical - not defined Live birth: Yes Multiples: Yes Complications: NR | Total | 63 | 88 | 151
Dale, Fiorentino, de Simone, et al., 2002 #620 | | | Definition(s) of outcome(s): Pregnancy: Clinical - not defined Live birth: Yes Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.60 | 0.40 | 0.89
De Camargo Martins, Baruffi, Mauri, et al., 2004 #9960 | Geographical location: São Paolo, Brazil Study dates: NR Size of population (no. of patients): 100 Number of cycles analyzed: 100 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - All underwent ICSI; - Mock transfer performed cycle prior to transfer; - Frydman catheter used in all patients; - U/S group: Embryos expelled when catheter tip within 0.5–1.5 cm of fundus, confirmed by U/S; - Control: Embryos expelled at catheter length determined in previous cycle | Age (mean [SD]): U/S: 32.1 (4.1) Control: 32.0 (3.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Transfer judged to be easy (no need for cervical manipulation) during mock transfer in previous cycle Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Miscarriage | 1) Pregnancy: | | | | Comments:; - No a priori sample size calculation; - Authors acknowledge study underpowered; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
De Camargo Martins, Baruffi, Mauri, et al., 2004 #9960 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Miscarriage | | Preg + | Preg -
De Camargo Martins, Baruffi, Mauri, et al., 2004 #9960 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Miscarriage | Ultrasound | 21 | 29 | 50
De Camargo Martins, Baruffi, Mauri, et al., 2004 #9960 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Miscarriage | Clinical touch | 15 | 35 | 50
De Camargo Martins, Baruffi, Mauri, et al., 2004 #9960 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Miscarriage | | 36 | 64 | 100
De Camargo Martins, Baruffi, Mauri, et al., 2004 #9960 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Miscarriage | | | Lower 95% CI | Upper 95 % CI
De Camargo Martins, Baruffi, Mauri, et al., 2004 #9960 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Miscarriage | Rel risk | 1.40 | 0.82 | 2.39
3) Miscarriage rate higher in control group, but denominator not reported.
De Placido, Alviggi, Perino, et al., 2005 #9690 | Geographical location: Italy (multicenter) Study dates: Feb 2003 – Dec 2003 Size of population: 130 Number of cycles analyzed: 130 Number of cycles per patient: 1.00 Study type: RCT Interventions: Compared the use of combine rLH and rFSH vs. rFSH step-up protocol for pts who initially have inadequate ovarian response to rFSH Grp a = combine rLH and rFSH Grp b = rFSH step-up protocol | Age: Mean (SD): Grp a: 31.5 (3.9) Grp b: 30.4 (4.1) Range: 18–37 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor:; - Grp a: 51.5; - Grp b: 48.4; Tubal factor:; - Grp a: 21.7; - Grp b: 25.6; Combined male and tubal factor:; - Grp a: 20.1; - Grp b: 21.8; Inclusion criteria:; - Age 18–37; - Menstrual cycle ranging from 24d–35d; - Day3 FSH ≤ 9 IU/L; - Hysteroscopic evidence of a normal uterine cavity within the last 6 mos; - Using GnRH agonist long protocol; Exclusion criteria:; - BMI < 18 or > 28; - Biochemical and/or ultrasonographic evidence of PCOS; - Stage III–IV endometriosis; - Chromosomal abnormalities; - Endocrinological and/or autoimmune disorder; - More than 2 previously unsuccessful IVF or ICSI; - Presence of only 1 ovary | Definition(s) of outcome(s): Ongoing pregnancy: Pregnancy reaching wk 12 Live birth: NR Multiples: NR Complications: NR | 1) Ongoing pregnancy rate: | | | | Comments:; - Results not reported as intent-to-treat (cancelled cycles not included); - Reported rates do not match calculated rates; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
De Placido, Alviggi, Perino, et al., 2005 #9690 | | | Definition(s) of outcome(s): Ongoing pregnancy: Pregnancy reaching wk 12 Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
De Placido, Alviggi, Perino, et al., 2005 #9690 | | | Definition(s) of outcome(s): Ongoing pregnancy: Pregnancy reaching wk 12 Live birth: NR Multiples: NR Complications: NR | rLH | 19 | 46 | 65
De Placido, Alviggi, Perino, et al., 2005 #9690 | | | Definition(s) of outcome(s): Ongoing pregnancy: Pregnancy reaching wk 12 Live birth: NR Multiples: NR Complications: NR | rFSH | 13 | 52 | 65
De Placido, Alviggi, Perino, et al., 2005 #9690 | | | Definition(s) of outcome(s): Ongoing pregnancy: Pregnancy reaching wk 12 Live birth: NR Multiples: NR Complications: NR | | 32 | 98 | 130
De Placido, Alviggi, Perino, et al., 2005 #9690 | | | Definition(s) of outcome(s): Ongoing pregnancy: Pregnancy reaching wk 12 Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 1.46 | 0.79 | 2.71
De Placido, Mollo, Alviggi, et al., 2001 #4320 | Geographical location: Naples, Italy Study dates: Nov 1999 – July 2000 Size of population: 43 Number of cycles analyzed: 43 Number of cycles per patient: 1.00 Study type: RCT Interventions: Investigated the effects of adding hMG during ovarian stimulation (for IVF) in normoovulatory normogonadotrophic pts showing an initial suboptimal response to standard long protocol using rFSH. Group A: rFSH is substituted by HMG Group B: dose of rFSH increased from 150 to 375 IU | Age: Mean (SD): Grp A: 31.65 (3.80) Grp B. 30.44 (3.84 Race/ethnicity (n [%]): Caucasian (Italian) 100 Diagnoses (n [%]): Male factor:; - Grp A: 35; - Grp B: 34.8; Tubal factor:; - Grp A: 35; - Grp B: 30.4; Combined male and tubal factors; - Grp A: 10; - Grp B: 21.7; Inclusion criteria:; - Menstrual cycle range 24d–35d; - Normal uterine cavity (by hysteroscopy); Exclusion criteria:; - Basal FSH. 10 IU/L; - Age ≥ 37 yr; - BMI .29; - Biochemical and/or u/s evidence of PCOS; - Stage III–IV endometriosis; - Autoimmune disease; - Thyroid disease; - Chromosomal abnormality; - One ovary | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy rate: | | | | Comments:; - Low power for pregnancy; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
De Placido, Mollo, Alviggi, et al., 2001 #4320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments:; - Low power for pregnancy; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
De Placido, Mollo, Alviggi, et al., 2001 #4320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | hMG | 10 | 10 | 20 | Comments:; - Low power for pregnancy; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
De Placido, Mollo, Alviggi, et al., 2001 #4320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | rFSH | 8 | 15 | 23 | Comments:; - Low power for pregnancy; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
De Placido, Mollo, Alviggi, et al., 2001 #4320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 18 | 25 | 43 | Comments:; - Low power for pregnancy; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
De Placido, Mollo, Alviggi, et al., 2001 #4320 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments:; - Low power for pregnancy; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.44 | 0.71 | 2.93
De Placido, Mollo, Clarizia, et al., 2006 #51460 | Geographical location: Naples, Italy Study dates: July 2002 and Feb 2004 Size of population (no. of patients): 133 Number of cycles analyzed: 133 Number of cycles per patient: 1.0 Study type: RCT Interventions: Antagonist: Of the GnRH-ant cetrorelix 0.125 mg/day administered for 2 days, beginning when at least one follicle ≥ 14 mm was present; thereafter, the GnRH-ant 0.25 mg/day until exogenous hCG administration. On the same day of GnRH-ant administration, a daily dose of 150 IU of rec-LH added until the day of hCG. Agonist: Triptorelin 0.1 mg SC, beginning on the same day of the first rec-FSH administration. In addition, a dose of 150 IU/day of rec-LH added when at least one follicle reached 14 mm. When at least one follicle reached 18–20 mm in diameter, hCG 10,000 IU IM) of hCG given to trigger ovulation. | Age: Mean (SD): Antagonist: 37.2 (4.1) Agonist: 37.3 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Age ≥ 37 years or day 2 FSH (basal FSH) serum concentration ≥ 9 IU/L; menstrual cycles ranging from 24–35 days (intraindividual variability ± 3 days), hysteroscopic evidence of a normal uterine cavity, couples undergoing ICSI. Exclusion criteria: BMI ≥ 26 kg/m2; biochemical or US evidence of polycystic ovary syndrome, and stage III–IV endometriosis according to the revised American Fertility Society classification (rAFS, 1985); inflammatory, autoimmune, and chromosomal disorders; endocrine and metabolic disease, including hyperprolactinemia; or the presence of only one ovary | Definition(s) of outcome(s): Ongoing pregnancy: Not defined Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - (not mentioned) Dropout rate < 20%: + Adequacy of randomization concealment: - (not mentioned)
De Placido, Mollo, Clarizia, et al., 2006 #51460 | | | Definition(s) of outcome(s): Ongoing pregnancy: Not defined Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Ongoing Preg + | Ongoing Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - (not mentioned) Dropout rate < 20%: + Adequacy of randomization concealment: - (not mentioned)
De Placido, Mollo, Clarizia, et al., 2006 #51460 | | | Definition(s) of outcome(s): Ongoing pregnancy: Not defined Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Antagonist | 14 | 53 | 67 | Comments: None Quality assessment: Randomization method: + Blinding: - (not mentioned) Dropout rate < 20%: + Adequacy of randomization concealment: - (not mentioned)
De Placido, Mollo, Clarizia, et al., 2006 #51460 | | | Definition(s) of outcome(s): Ongoing pregnancy: Not defined Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Agonist | 17 | 49 | 66 | Comments: None Quality assessment: Randomization method: + Blinding: - (not mentioned) Dropout rate < 20%: + Adequacy of randomization concealment: - (not mentioned)
De Placido, Mollo, Clarizia, et al., 2006 #51460 | | | Definition(s) of outcome(s): Ongoing pregnancy: Not defined Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 31 | 102 | 133 | Comments: None Quality assessment: Randomization method: + Blinding: - (not mentioned) Dropout rate < 20%: + Adequacy of randomization concealment: - (not mentioned)
De Placido, Mollo, Clarizia, et al., 2006 #51460 | | | Definition(s) of outcome(s): Ongoing pregnancy: Not defined Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - (not mentioned) Dropout rate < 20%: + Adequacy of randomization concealment: - (not mentioned)
De Placido, Mollo, Clarizia, et al., 2006 #51460 | | | Definition(s) of outcome(s): Ongoing pregnancy: Not defined Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.81 | 0.44 | 1.51 | Comments: None Quality assessment: Randomization method: + Blinding: - (not mentioned) Dropout rate < 20%: + Adequacy of randomization concealment: - (not mentioned)
De Placido, Mollo, Clarizia, et al., 2006 #51460 | | | Definition(s) of outcome(s): Ongoing pregnancy: Not defined Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 2) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - (not mentioned) Dropout rate < 20%: + Adequacy of randomization concealment: - (not mentioned)
De Placido, Mollo, Clarizia, et al., 2006 #51460 | | | Definition(s) of outcome(s): Ongoing pregnancy: Not defined Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - (not mentioned) Dropout rate < 20%: + Adequacy of randomization concealment: - (not mentioned)
De Placido, Mollo, Clarizia, et al., 2006 #51460 | | | Definition(s) of outcome(s): Ongoing pregnancy: Not defined Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Antagonist | 12 | 55 | 67 | Comments: None Quality assessment: Randomization method: + Blinding: - (not mentioned) Dropout rate < 20%: + Adequacy of randomization concealment: - (not mentioned)
De Placido, Mollo, Clarizia, et al., 2006 #51460 | | | Definition(s) of outcome(s): Ongoing pregnancy: Not defined Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Agonist | 16 | 50 | 66 | Comments: None Quality assessment: Randomization method: + Blinding: - (not mentioned) Dropout rate < 20%: + Adequacy of randomization concealment: - (not mentioned)
De Placido, Mollo, Clarizia, et al., 2006 #51460 | | | Definition(s) of outcome(s): Ongoing pregnancy: Not defined Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 28 | 105 | 133 | Comments: None Quality assessment: Randomization method: + Blinding: - (not mentioned) Dropout rate < 20%: + Adequacy of randomization concealment: - (not mentioned)
De Placido, Mollo, Clarizia, et al., 2006 #51460 | | | Definition(s) of outcome(s): Ongoing pregnancy: Not defined Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - (not mentioned) Dropout rate < 20%: + Adequacy of randomization concealment: - (not mentioned)
Rel risk | 0.74 | 0.38 | 1.44
Demirol, Guven, Baykal, et al., 2006 #51520 | Geographical location: Ankara, Turkey Study dates: January 2001–March 2005 Size of population (no. of patients): 99 Number of cycles analyzed: 99 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - Surgery: laparoscopic drainage of endometrioma, dissection of pseudocapsule, control of bleeding with bipolor coagulation, with stimulation 3 months later; - Control: no surgery, immediate ISCI, endometrioma drained at time of oocyte retrieval | Age: Mean (SD): Surgery 35.2 (0.3); control: 34.9 (0.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Endometriosis: 100% Inclusion criteria:; - Single or unilateral multiple endometriomas ≥ 3cm, < 6 cm, dx'ed by transvaginal US; - Scheduled for ICSI; Exclusion criteria:; - Bilateral endometriomas; - Suture use during laparoscopy | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments:; - Randomization method not reported; Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:- (NR)
Demirol, Guven, Baykal, et al., 2006 #51520 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments:; - Randomization method not reported; Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:- (NR)
Demirol, Guven, Baykal, et al., 2006 #51520 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Surgery | 17 | 32 | 49 | Comments:; - Randomization method not reported; Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:- (NR)
Demirol, Guven, Baykal, et al., 2006 #51520 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Control | 19 | 31 | 50 | Comments:; - Randomization method not reported; Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:- (NR)
Demirol, Guven, Baykal, et al., 2006 #51520 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 36 | 63 | 99 | Comments:; - Randomization method not reported; Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:- (NR)
Demirol, Guven, Baykal, et al., 2006 #51520 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments:; - Randomization method not reported; Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:- (NR)
Rel risk | 0.91 | 0.54 | 1.54
Devroey, Fauser, Platteau, et al., 2004 #13260 | Geographical location: Brussels and Ghent, Belgium; Rotterdam, the Netherlands Study dates: NR Size of population (no. of patients): 98 Number of cycles analyzed: 98 Number of cycles per patient: 1.0 Study type: RCT Interventions: GnRH antagonist +; (a) fixed daily dose of 150 IU rFSH,; (b) 120 IU FSH-CTP (long-acting), followed 1 week later by fixed daily 150 IU rFSH; (c) 180 IU FSH-CTP + 150 IU rFSH 1 week later; (d) 240 IU rFSH + 150 IU rFSH 1 week later | Age: Mean (SD): rFSH: 32.1 (4.3) 120 FSH-CTP: 30.4 (3.8) 180 FSH-CTP: 31.5 (3.8) 240 FSH-CTP: 33.4 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 20 (20%) Endometriosis: 3 (3%) Male factor: 40 (41%) Tubal factor: 24 (24%) Other: Combined 5 (5%) Inclusion criteria:; - Undergoing COH for IVF/ICSI; - Age 18–39; - Ovulatory; - BMI 18–29; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | 1) Ongoing pregnancy - daily 150 IU rFSH vs. 120 IU FSH-CTP: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | Preg+ | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | 120 IU FSH-CTP | 4 | 21 | 25 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | rFSH | 10 | 14 | 24 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Total | 14 | 35 | 49 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 0.38 | 0.14 | 1.06 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | 2) Ongoing pregnancy - 150 IU rFSH vs. 180 IU FSH-CTP: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | Preg+ | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | 180 IU FSH-CTP | 5 | 19 | 24 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | rFSH | 10 | 14 | 24 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Total | 15 | 33 | 48 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 0.50 | 0.20 | 1.25 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | 3) Ongoing pregnancy - 150 IU rFSH vs. 2400 IU FSH-CTP: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | Preg+ | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | 240 IU FSH-CTP | 6 | 19 | 25 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | rFSH | 10 | 14 | 24 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Total | 16 | 33 | 49 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Devroey, Fauser, Platteau, et al., 2004 #13260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 0.58 | 0.25 | 1.34 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
4) OHSS: 2 cases each in rFSH, 120 FSH-CTP, and 240 FSH-CTP
Dickey, Nichols, Steinkampf, et al., 2003 #11410 | Geographical location: New Orleans & Baton Rouge, LA, Greenville, SC; Birmingham, AL; Plymouth Meeting, PA; Valencia, CA; Odessa, TX; Charlotte, NC Study dates: NR Size of population (no. of patients): 238 Number of cycles analyzed: 238 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized after GnRH down regulation to identical doses of; (a) highly purified human-derived FSH, or; (b) recombinant follitropijn-β; 225 IU sc for 5 days, dose adjusted to maximum of 450 IU/day, maximum duration 12 days | Age: Mean (SD): human FSH 32.0 (3.9), follitropijn-β 32.5 (3.7) Race/ethnicity (n [%]): Diagnoses (n [%]): Unexplained infertility: 28% Endometriosis: 16% Male factor: 4% Tubal factor: 53% Inclusion criteria:; - Age 18–39; - Non-smoking; - Normal hormones/ultrasound; - Normal semen (partner or donor); Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—intrauterine fetal sac with heart beat Live birth: Yes Multiples: NR Complications: NR | 1) Clinical pregnancy (Intention to treat) | | | | Comments:; - Combined results from 2 separate protocols; individual results not provided; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Dickey, Nichols, Steinkampf, et al., 2003 #11410 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—intrauterine fetal sac with heart beat Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Dickey, Nichols, Steinkampf, et al., 2003 #11410 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—intrauterine fetal sac with heart beat Live birth: Yes Multiples: NR Complications: NR | HP-hFSH | 51 | 69 | 120
Dickey, Nichols, Steinkampf, et al., 2003 #11410 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—intrauterine fetal sac with heart beat Live birth: Yes Multiples: NR Complications: NR | follitropijn-β | 45 | 73 | 118
Dickey, Nichols, Steinkampf, et al., 2003 #11410 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—intrauterine fetal sac with heart beat Live birth: Yes Multiples: NR Complications: NR | | 96 | 142 | 238
Dickey, Nichols, Steinkampf, et al., 2003 #11410 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—intrauterine fetal sac with heart beat Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Dickey, Nichols, Steinkampf, et al., 2003 #11410 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—intrauterine fetal sac with heart beat Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.11 | 0.82 | 1.52
Dickey, Nichols, Steinkampf, et al., 2003 #11410 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—intrauterine fetal sac with heart beat Live birth: Yes Multiples: NR Complications: NR | 2) Live birth (intention to treat)
Dickey, Nichols, Steinkampf, et al., 2003 #11410 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—intrauterine fetal sac with heart beat Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Dickey, Nichols, Steinkampf, et al., 2003 #11410 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—intrauterine fetal sac with heart beat Live birth: Yes Multiples: NR Complications: NR | HP-hFSH | 42 | 78 | 120
Dickey, Nichols, Steinkampf, et al., 2003 #11410 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—intrauterine fetal sac with heart beat Live birth: Yes Multiples: NR Complications: NR | follitropijn-β | 38 | 80 | 118
Dickey, Nichols, Steinkampf, et al., 2003 #11410 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—intrauterine fetal sac with heart beat Live birth: Yes Multiples: NR Complications: NR | | 80 | 158 | 238
Dickey, Nichols, Steinkampf, et al., 2003 #11410 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—intrauterine fetal sac with heart beat Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 1.09 | 0.76 | 1.55
Dieterle, Ying, Hatzmann, et al., 2006 #51570 | Geographical location: Dortmund, Germany Study dates: NR Size of population (no. of patients): 225 Number of cycles analyzed: 225 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - All underwent COH with GnRH agonist (nafarelin), hMG or rFSH; no more than 3 embryos transferred; - Randomized to active or placebo acupuncture for 30 minutes, immediately after embryo transfer, and 3 days later; - Active acupuncture: performed on acupuncture points believed to be associated with fertility, along with placing of Chinese herbal medicine (seed of Caryophyllaceae) to ear; - Placebo—acupuncture applied to points not associated with fertility | Age: Mean (SD): Acupuncture: 35.1 (3.8); placebo:34.7 (4.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: Endometriosis: 18% acupuncture, 11% control Male factor: 58% acupuncture, 60% control Tubal factor: 35% acupuncture, 38% control Other - not specified: acupuncture 13%, control 11% Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on TV US 4–6 weeks after transfer Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments:; - Sample size based on clinical pregnancy rate, powered to detect; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Dieterle, Ying, Hatzmann, et al., 2006 #51570 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on TV US 4–6 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments:; - Sample size based on clinical pregnancy rate, powered to detect; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Dieterle, Ying, Hatzmann, et al., 2006 #51570 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on TV US 4–6 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Active acupuncture | 39 | 77 | 116 | Comments:; - Sample size based on clinical pregnancy rate, powered to detect; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Dieterle, Ying, Hatzmann, et al., 2006 #51570 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on TV US 4–6 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Control | 17 | 92 | 109 | Comments:; - Sample size based on clinical pregnancy rate, powered to detect; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Dieterle, Ying, Hatzmann, et al., 2006 #51570 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on TV US 4–6 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | 56 | 169 | 225 | Comments:; - Sample size based on clinical pregnancy rate, powered to detect; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Dieterle, Ying, Hatzmann, et al., 2006 #51570 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on TV US 4–6 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments:; - Sample size based on clinical pregnancy rate, powered to detect; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Dieterle, Ying, Hatzmann, et al., 2006 #51570 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on TV US 4–6 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Rel risk | 2.16 | 1.30 | 3.58 | Comments:; - Sample size based on clinical pregnancy rate, powered to detect; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Dieterle, Ying, Hatzmann, et al., 2006 #51570 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on TV US 4–6 weeks after transfer Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy: | | | | Comments:; - Sample size based on clinical pregnancy rate, powered to detect; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Dieterle, Ying, Hatzmann, et al., 2006 #51570 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on TV US 4–6 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments:; - Sample size based on clinical pregnancy rate, powered to detect; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Dieterle, Ying, Hatzmann, et al., 2006 #51570 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on TV US 4–6 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Study drug | 33 | 83 | 116 | Comments:; - Sample size based on clinical pregnancy rate, powered to detect; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Dieterle, Ying, Hatzmann, et al., 2006 #51570 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on TV US 4–6 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Control | 15 | 94 | 109 | Comments:; - Sample size based on clinical pregnancy rate, powered to detect; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Dieterle, Ying, Hatzmann, et al., 2006 #51570 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on TV US 4–6 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | 48 | 177 | 225 | Comments:; - Sample size based on clinical pregnancy rate, powered to detect; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Dieterle, Ying, Hatzmann, et al., 2006 #51570 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on TV US 4–6 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments:; - Sample size based on clinical pregnancy rate, powered to detect; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 2.07 | 1.19 | 3.59
Dor, Bider, Shulman, et al., 2000 #7810 | Geographical location: Tel Hashomer, Israel Study dates: NR Size of population: Grp 1: 26 Grp 2: 24 Grp 3: 24 Number of cycles analyzed: 74 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: HMG administration only Grp 2: Downregulation with intranasal Buserelin followed by HMG Grp 3: Downregulation with IM Triptorelin followed by HMG. All women underwent IVF | Age: Grp 1 Mean (SEM):27.9 (0.7) Grp 2: Mean (SEM): 30.2 (0.9) Grp 3: Mean (SEM): 29.5 (0.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Tubal or unexplained infertility Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 1) Pregnancy rate Grp 1 vs 2: | | | | Comments:; - Pregnancy was not the primary outcome and the study is not powered for such; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Buserlin | 6 | 18 | 24
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | hMG only | 5 | 21 | 26
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | 11 | 39 | 50
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.30 | 0.46 | 3.71
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 2) Preg rate Grp 1 vs 3:
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Triptorelin | 7 | 17 | 24
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | hMG only | 5 | 21 | 26
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | 12 | 38 | 50
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.52 | 0.56 | 4.14
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 3) Preg rate Grp 2 vs 3:
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Buserelin/HMG | 6 | 18 | 24
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Triptorelin/HMG | 7 | 17 | 24
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Total | 13 | 35 | 48
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Dor, Bider, Shulman, et al., 2000 #7810 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.86 | 0.34 | 2.18
4) Delivery rate also shows no sig difference among the grps
Drakakis, Loutradis, Kallianidis, et al., 2005 #41650 | Geographical location: Multicenter, Greece Study dates: NR Size of population: 46 Number of cycles analyzed: 46 Number of cycles per patient: 1.00 Study type: RCT Interventions: Objective: to examine whether exogenous LH (given on the first 4 days of the cycle) administration has a beneficial effect on the quality of oocytes, fertilization potential and pregnancy rate in IVF cycle. This is a GnRH agonist long protocol. Randomization: Compare the use of 1 amp of hMG (75 IU FSH+75 IU LH)+ r-FSH 150 IU with 200 IU of r-FSH in the first 4 days of stimulation cycle. Both grps received 200 of FSH afterward. | Age: Mean (SD): rFSH: 33.0 (3.7) rFSH+hMG 32.4 (3.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Paper did not state the percentage of the diagnosis in each grp. The paper just said the the diagnosis for each pt is either tubal or male factor. Inclusion criteria: First IVF Cycle Either tubal or male factor Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy rate: | | | | Comments: There are many factors that might effect embryo quality/pregnancy outcome that the paper did not state:; 1) Percentage of pts with male infertility in each grp.; 2) Other diagnosis that pts might have (PCOS, endometriosis); 3) Paper also did not state the work up for infertility in the population in this study.; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: - Adequacy of randomization concealment: +
Drakakis, Loutradis, Kallianidis, et al., 2005 #41650 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total
Drakakis, Loutradis, Kallianidis, et al., 2005 #41650 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | rFSH + hMG | 5 | 19 | 24
Drakakis, Loutradis, Kallianidis, et al., 2005 #41650 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | rFSH | 6 | 16 | 22
Drakakis, Loutradis, Kallianidis, et al., 2005 #41650 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 11 | 35 | 46
Drakakis, Loutradis, Kallianidis, et al., 2005 #41650 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Drakakis, Loutradis, Kallianidis, et al., 2005 #41650 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.76 | 0.27 | 2.15
2) There are statistically significant more mature oocytes and no. of transferable embryos in rFSH+hMG group when compared to the control.
Driscoll, Tyler, Hangan, et al., 2000 #58120 | Geographical location: Westmead, Australia, and Auckland, New Zealand Study dates: NR Size of population (no. of patients): 84 Number of cycles analyzed: 84 Number of cycles per patient: 1.0 Study type: RCT Interventions: GnRH down regulation, rFSH hyperstimulation, with either (a) 5000 IU uhCG + placebo or (b) 5000 IU rhCG + placebo for ovarian maturation | Age: Mean (SD): Overall: 32.4 (4) Range: 21–38 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR in detail; male factor only in 53% rhCG, 45% uhCG Inclusion criteria:; - Candidate for IVF/ICSI; - Regular cycles; Exclusion criteria:; - Systemic disease; - BMI > 30; - PCOS; - History of OHSS; - History of poor response to COH; - >3 previous attempts; - Any treatment in past 2 months | Definition(s) of outcome(s): Pregnancy: Sac on ultrasound at 42 days Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Driscoll, Tyler, Hangan, et al., 2000 #58120 | | | Definition(s) of outcome(s): Pregnancy: Sac on ultrasound at 42 days Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Driscoll, Tyler, Hangan, et al., 2000 #58120 | | | Definition(s) of outcome(s): Pregnancy: Sac on ultrasound at 42 days Live birth: NR Multiples: NR Complications: NR | uhCG | 6 | 38 | 44 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Driscoll, Tyler, Hangan, et al., 2000 #58120 | | | Definition(s) of outcome(s): Pregnancy: Sac on ultrasound at 42 days Live birth: NR Multiples: NR Complications: NR | rhCG | 7 | 33 | 40 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Driscoll, Tyler, Hangan, et al., 2000 #58120 | | | Definition(s) of outcome(s): Pregnancy: Sac on ultrasound at 42 days Live birth: NR Multiples: NR Complications: NR | Total | 13 | 71 | 84 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Driscoll, Tyler, Hangan, et al., 2000 #58120 | | | Definition(s) of outcome(s): Pregnancy: Sac on ultrasound at 42 days Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Rel risk | 0.78 | 0.29 | 2.12
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | Geographical location: Ankara, Turkey Study dates: 2001-2002 Size of population (no. of patients): 187 Number of cycles analyzed: 187 Number of cycles per patient: 1.00 Study type: RCT Interventions:; - Randomized on day of embryo transfer to 1 of 4 interventions:; A 100 mg/day aspirin; B 10 mg/day prednisolone; C 100 mg/day aspirin + 10 mg/day prednisolone; D No treatment (unclear if placebo used—not stated in methods) | Age: Mean (SD): 31.8 (6.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Endometriosis: 3 (1.6%) Male factor: 90 (48.1%) Tubal factor: 27 (14.4%) PCOS: 6 (3.2%) Inclusion criteria:; - 1^st^ ICSI cycle; Exclusion criteria:; - Contraindication to aspirin or steroid | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: aspirin vs control: | | | | Comments:; - Abstract states placebo, but not described in methods; - No adjustment to sample size or analysis for multiple comparisons; Quality assessment: Randomization method: + Blinding: ? (unclear from paper) Dropout rate < 20%: + Adequacy of randomization concealment: +
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | Study drug | 11 | 30 | 41
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | Control | 14 | 26 | 40
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | | 25 | 56 | 81
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.77 | 0.40 | 1.48
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | 2) Clinical pregnancy: prednisolone vs control:
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | Study drug | 22 | 28 | 50
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | Control | 14 | 26 | 40
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | | 36 | 54 | 90
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.26 | 0.74 | 2.13
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | 3) Clinical pregnancy: prednisolone + aspirin vs control:
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | Study drug | 19 | 37 | 56
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | Control | 14 | 26 | 40
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | | 33 | 63 | 96
Duvan, Ozmen, Satiroglu, et al., 2006 #51650 | | | Definition(s) of outcome(s): Pregnancy: + hCG with doubling Clinical pregnancy: gestational sac Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 0.97 | 0.55 | 1.69
El-Toukhy, Taylor, Khalaf, et al., 2004 #13690 | Geographical location: London, UK Study dates: Jan 1998 and July 2001 Size of population (no. of patients): 234 Number of cycles analyzed: 234 Number of cycles per patient: 1.0 Study type: RCT Interventions: Pituitary suppression prior to steroid hormone administration: Buserelin nasal spray starting in the mid-luteal phase (day 21) of the menstrual cycle. On day 1 of subsequent menstruation, estrogen stimulation was initiated using oral estradiol valerate 6 mg daily in two divided doses. Steroid supplementation without prior pituitary desensitization: Estrogen 6mg/day stimulation on day 1 of menstruation. | Age: Mean (SD): 33 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Tubal factor: 35% Inclusion criteria: Previous IVF with or without ICSI with embryo cryopreservation, had regular menstrual cycles Exclusion criteria: Patients using cryo-thawed embryos created from donated oocytes were not included | Definition(s) of outcome(s): Pregnancy: Observation on US scanning of a gestational sac with fetal heart beat between 4 and 5 weeks after the positive pregnancy test Live birth: Yes Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
El-Toukhy, Taylor, Khalaf, et al., 2004 #13690 | | | | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
El-Toukhy, Taylor, Khalaf, et al., 2004 #13690 | | | | GnRH | 44 | 73 | 117 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
El-Toukhy, Taylor, Khalaf, et al., 2004 #13690 | | | | No GnRH | 28 | 89 | 117 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
El-Toukhy, Taylor, Khalaf, et al., 2004 #13690 | | | | Total | 72 | 162 | 234 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
El-Toukhy, Taylor, Khalaf, et al., 2004 #13690 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
El-Toukhy, Taylor, Khalaf, et al., 2004 #13690 | | | | Rel risk | 1.57 | 1.05 | 2.34 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
El-Toukhy, Taylor, Khalaf, et al., 2004 #13690 | | | | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
El-Toukhy, Taylor, Khalaf, et al., 2004 #13690 | | | | | Live birth + | Live birth - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
El-Toukhy, Taylor, Khalaf, et al., 2004 #13690 | | | | GnRH | 23 | 94 | 117 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
El-Toukhy, Taylor, Khalaf, et al., 2004 #13690 | | | | No GnRH | 10 | 107 | 117 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
El-Toukhy, Taylor, Khalaf, et al., 2004 #13690 | | | | Total | 33 | 201 | 234 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
El-Toukhy, Taylor, Khalaf, et al., 2004 #13690 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 2.30 | 1.15 | 4.62
Emiliani, Fasano, Vandamme, et al., 2005 #51750 | Geographical location: Brussels, Belgium Study dates: NR Size of population (no. of patients): 187 Number of cycles analyzed: 196 Number of cycles per patient: 1.06 Study type: RCT Interventions:; - Undergoing single embryo transfer; - Randomized on day of retrieval to; (a) early cleavage assessed 25 hours after insemination; if positive, used as criterion in addition to day 2 embyro score described below; vs; (b) scoring only:; 4: 2-cell embryo with regular blastomeres and no anucleate fragments. 3: 2-cell embryo with uneven blastomeres, or fragments <l/3 of the embryonic surface 2, 1: 2-cell embryo with uneven blastomeres | Age: Mean (SD): Early cleavage: 30.3 (3.3); score only: 30.1 (3.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 36; - Undergoing 1^st^ IVF or ICSI cycle; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac 28 days after retrieval Live birth: Yes Multiples: NR Complications: NR | 1) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment:-
Emiliani, Fasano, Vandamme, et al., 2005 #51750 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac 28 days after retrieval Live birth: Yes Multiples: NR Complications: NR | | Live birth + | Live birth - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment:-
Emiliani, Fasano, Vandamme, et al., 2005 #51750 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac 28 days after retrieval Live birth: Yes Multiples: NR Complications: NR | Early cleavage | 26 | 64 | 90 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment:-
Emiliani, Fasano, Vandamme, et al., 2005 #51750 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac 28 days after retrieval Live birth: Yes Multiples: NR Complications: NR | Score only | 24 | 70 | 94 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment:-
Emiliani, Fasano, Vandamme, et al., 2005 #51750 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac 28 days after retrieval Live birth: Yes Multiples: NR Complications: NR | | 50 | 134 | 184 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment:-
Emiliani, Fasano, Vandamme, et al., 2005 #51750 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac 28 days after retrieval Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment:-
Rel risk | 1.13 | 0.70 | 1.82
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | Geographical location: Farmington, Conn Study dates: Aug 2004–March 2006 Size of population (no. of patients): 65 Number of cycles analyzed: 65 Number of cycles per patient: 1.0 Study type: RCT Interventions: All pretreated with OCPs and GnRH agonist; then rFSH + GnRH antagonist (Ganirelix). Randomized to hCG or leuprolide as ovulation trigger when 2–3 follicles ≥ 18 mm. | Age: Mean (SD): hCG: 33.1 ± 3.6; Leuprolide: 32.0 ± 3.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 2 (3.1%) Endometriosis: 2 (3.1%) Male factor: 15 (23.1%) Tubal factor: 18 (27.7%) PCOS: 28 (43,1%) Inclusion criteria:; - Age 20–39 years at the time of screening; - Normal early follicular phase serum FSH concentration (%10.0 IU/L); - Undergoing first cycle of IVF with either PCOS or PCOM or undergoing a subsequent cycle with a history of high response in a previous IVF cycle; Exclusion criteria: Hypogonadotropic hypogonadism | Definition(s) of outcome(s): Pregnancy: Gestational sac + heart rate on ultrasound at 7 weeks; ongoing pregnancy: continuing after 12 weeks Live birth: NR Multiples: NR Complications: OHSS (Golan criteria) | 1) All OHSS: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | | OHSS + | OHSS - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | GnRH agonist | 0 | 33 | 33 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | hCG | 10 | 22 | 32 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | Total | 10 | 55 | 65 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | Rel risk | 0.05 | 0.00 | 0.76 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | 2) Moderate-severe OHSS: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | | OHSS + | OHSS - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | GnRH agonist | 0 | 33 | 33 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | hCG | 5 | 27 | 32 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | Total | 5 | 60 | 65 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | Rel risk | 0.09 | 0.01 | 1.53 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | 3) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | GnRH agonist | 17 | 16 | 33 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | hCG | 15 | 17 | 32 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | Total | 32 | 33 | 65 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | Rel risk | 1.10 | 0.67 | 1.80 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | 4) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | GnRH agonist | 16 | 17 | 33 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | hCG | 14 | 18 | 32 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | Total | 30 | 35 | 65 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Engmann, DiLuigi, Schmidt, et al., 2008 #70940 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.11 | 0.65 | 1.88
Escudero, Bosch, Crespo, et al., 2004 #13600 | Geographical location: Valencia, Spain Study dates: Oct 2001 and June 2002 Size of population (no. of patients): 109 Number of cycles analyzed: 109 Number of cycles per patient: 1 Study type: RCT Interventions: Follicle > 14: GnRH-antagonist when the leading follicle reached a mean diameter of 14 mm. Day 6: GnRH-antagonist on stimulation day 6 | Age: Mean (SD): 32.1 (3.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 93 (85.3%) Tubal factor: 16 (14.7%) Inclusion criteria: Age ≤ 35 years; regular menstrual cycles ranging from 24–32 days; normal basal serum FSH (≤ 10 IU/L) LH (≤ 10 IU/L), and E2 (≤ 60 pg/mL) levels; body mass index (BMI) ≥ 30 kg/m2; no uterine (adenomyosis, müllerian malformations) or ovarian (polycystic ovarian syndrome [PCOS], endometriosis) abnormalities assessed by vaginal ultrasound Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Presence of a gestational sac with positive heartbeat Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Escudero, Bosch, Crespo, et al., 2004 #13600 | | | Definition(s) of outcome(s): Pregnancy: Presence of a gestational sac with positive heartbeat Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Escudero, Bosch, Crespo, et al., 2004 #13600 | | | Definition(s) of outcome(s): Pregnancy: Presence of a gestational sac with positive heartbeat Live birth: NR Multiples: NR Complications: NR | Day 6 | 26 | 25 | 51 | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Escudero, Bosch, Crespo, et al., 2004 #13600 | | | Definition(s) of outcome(s): Pregnancy: Presence of a gestational sac with positive heartbeat Live birth: NR Multiples: NR Complications: NR | Follicle >14 mm | 20 | 25 | 45 | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Escudero, Bosch, Crespo, et al., 2004 #13600 | | | Definition(s) of outcome(s): Pregnancy: Presence of a gestational sac with positive heartbeat Live birth: NR Multiples: NR Complications: NR | | 46 | 50 | 96 | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Escudero, Bosch, Crespo, et al., 2004 #13600 | | | Definition(s) of outcome(s): Pregnancy: Presence of a gestational sac with positive heartbeat Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Rel risk | 1.15 | 0.75 | 1.75
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | Geographical location: 22 centers from 6 countries: Germany, Denmark, Israel, Netherlands, Switzerland United Kingdom Study dates: May 1966 – Nov 2000 Size of population: 727 Number of cycles analyzed: 727 Number of cycles per patient: 1.00 Study type: RCT Interventions: Compare the efficacy of highly purified menotropin (Menopur) and rFSH in IVF/ICSI cycle | Age: Mean (SD): Menopur: 30.82 (4.21) FSH: 30.81 (4.16) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility:; - Menopur 11.0; - rFSH 13.6; Endometriosis:; - Menopur 2.3; - rFSH 2.4; Male factor:; - Menopur 67.3; - rFSH 65.8; Unilateral tubal factor:; - Menopur 3.8; - rFSH 2.7; Bilateral tubal factor:; - Menopur 13.4; - rFSH 14.1; Inclusion criteria:; - Infertility > 1 yr (except those with bilateral tubal occlusion and/or male factor infertility); - Eligible for IVF/ICSI; - Minimum of 1 menstrual cycle w/o treatment with fertility modifiers prior to prestudy exam; - Age 18–38; - Regular menstrual cycle 24d–35d; - No evidence of ovarian anomalies on u/s; - Normal uterus; - Normal baseline parameters for hematology/blood chemistry, and urinalysis within the last 12 mos; - Baseline endocrine values all within the last 12 mos; Exclusion criteria:; - Presence of a clinically relevant systemic disease, endocrinologic disorder, or ovarian cysts prior to IVF/ICSI procedures; - Contraindication to gonadotropins or GnRH antagonist; - More than 3 previously unsuccessful IVF/ICSI cycles; - BMI <18 or >29; - Smoking: 10 cigarettes per day; - History of alcohol abuse and/or other drugs; - Currently breast feeding, pregnant, or contraindication to pregnancy; - Diagnosis as a poor responder in gonadotropin-stimulated procedures; - History of OHSS type III during previous ART treatment; - Participation in any study within the last 30d | Definition(s) of outcome(s): Biochemical pregnancy: hCG positive test Clinical pregnancy: + fetal cardiac activity 4 wks after egg retrieval Ongoing pregnancy rate: Confirm clinical pregnancy at 10 wks after egg retrieval Live birth: NR Multiples: Yes Complications: OHSS | 1) Clinical pregnancy: (includes all randomized patients who began treatment): | | | | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | | Preg + | Preg - | | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | HP-hMG | 98 | 275 | 373 | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | rFSH | 78 | 276 | 354 | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | | 176 | 551 | 727 | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | Rel risk | 1.19 | 0.92 | 1.55 | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | 2) Ongoing pregnancy rate: | | | | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | | Preg + | Preg - | | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | HP-hMG | 87 | 286 | 373 | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | rFSH | 73 | 281 | 354 | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | | 160 | 567 | 727 | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | Rel risk | 1.13 | 0.86 | 1.49 | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | 3) Multiple gestation: | | | | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | | Multiple | Single | | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | HP-hMG | 30 | 65 | 95 | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | rFSH | 27 | 49 | 76 | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | | 57 | 114 | 171 | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Israeli Study Group on Highly Purified Menotropin versus Recombinant Follicle-Stimulating Hormone, 2002 #1070 | | | | Rel risk | 0.89 | 0.58 | 1.36 | Comments: Powered to detect 10% absolute difference in clinical pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
4) OHSS rates similar (1.9% HP-HPG, 1.2% rFSH)
European and Middle East Orgalutran Study Group, 2001 #5570 | Geographical location: Multicenter; countries include Austria, Egypt, France, Germany, Israel, Jordan, Spain, Switzerland, The Netherlands Study dates: NR Size of population: 355 Number of cycles analyzed: 355 Number of cycles per patient: 1.00 Study type: RCT Interventions: Compared the clinical outcome between using GnRH antagonist ganirelix and GnRH agonist long protocol | Age: Mean (SD): 29.9 Ganirelix 29.8 (4.3) Triptorelin 30.2 (4.2) Range: 18–39 Race/ethnicity (n [%]): Caucasian 97.9 Diagnoses (n [%]): Male factor:; - Ganirelix: 60.2; - Triptorelin: 63.1; Tubal factor:; - Ganirelix: 17.7; - Triptorelin: 16.2; Inclusion criteria:; - Female; - Age > 18 and < 39; - BMI 18–29; - Regular cycle; - Willing to give written consent; Exclusion criteria: NR | Definition(s) of outcome(s): Ongoing pregnancy: Pregnancy confirm by u/s at 12–16 wks after embryo transfer Live birth: NR Multiples: NR Complications: NR | 1) Ongoing pregnancy rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Middle East Orgalutran Study Group, 2001 #5570 | | | Definition(s) of outcome(s): Ongoing pregnancy: Pregnancy confirm by u/s at 12–16 wks after embryo transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Middle East Orgalutran Study Group, 2001 #5570 | | | Definition(s) of outcome(s): Ongoing pregnancy: Pregnancy confirm by u/s at 12–16 wks after embryo transfer Live birth: NR Multiples: NR Complications: NR | Ganirelix | 70 | 156 | 226 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Middle East Orgalutran Study Group, 2001 #5570 | | | Definition(s) of outcome(s): Ongoing pregnancy: Pregnancy confirm by u/s at 12–16 wks after embryo transfer Live birth: NR Multiples: NR Complications: NR | Triptorelin | 37 | 74 | 111 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Middle East Orgalutran Study Group, 2001 #5570 | | | Definition(s) of outcome(s): Ongoing pregnancy: Pregnancy confirm by u/s at 12–16 wks after embryo transfer Live birth: NR Multiples: NR Complications: NR | | 107 | 230 | 337 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European and Middle East Orgalutran Study Group, 2001 #5570 | | | Definition(s) of outcome(s): Ongoing pregnancy: Pregnancy confirm by u/s at 12–16 wks after embryo transfer Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.93 | 0.67 | 1.29
European rhCG Study Group, 2000 #58150 | Geographical location: Multicenter in France, Germany, Israel, Italy, the Netherlands, Sweden, UK Study dates: Feb 1995–Oct 1996 Size of population (no. of patients): 190 Number of cycles analyzed: 190 Number of cycles per patient: 1.0 Study type: RCT Interventions: GnRH down regulation, rFSH hyperstimulation, with either (a) 5000 IU uhCG + placebo or (b) 5000 IU rhCG + placebo for ovarian maturation | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 54 (28%) Endometriosis: 15 (8%) Male factor: 62 (33%) Tubal factor: 79 (42%) Inclusion criteria:; - Candidate for IVF/ICSI; - Regular cycles; - Normal semen analysis; Exclusion criteria:; - Systemic disease; - PCOS; - History of OHSS; - History of poor response to COH; - > 3 previous attempts; - Any treatment in past 2 months | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy not defined Live birth: NR Multiples: NR Complications: Injection site AEs | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European rhCG Study Group, 2000 #58150 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy not defined Live birth: NR Multiples: NR Complications: Injection site AEs | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European rhCG Study Group, 2000 #58150 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy not defined Live birth: NR Multiples: NR Complications: Injection site AEs | rhCG | 32 | 65 | 97 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European rhCG Study Group, 2000 #58150 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy not defined Live birth: NR Multiples: NR Complications: Injection site AEs | uhCG | 23 | 70 | 93 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European rhCG Study Group, 2000 #58150 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy not defined Live birth: NR Multiples: NR Complications: Injection site AEs | Total | 55 | 135 | 190 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European rhCG Study Group, 2000 #58150 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy not defined Live birth: NR Multiples: NR Complications: Injection site AEs | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European rhCG Study Group, 2000 #58150 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy not defined Live birth: NR Multiples: NR Complications: Injection site AEs | Rel risk | 1.33 | 0.85 | 2.10 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European rhCG Study Group, 2000 #58150 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy not defined Live birth: NR Multiples: NR Complications: Injection site AEs | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European rhCG Study Group, 2000 #58150 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy not defined Live birth: NR Multiples: NR Complications: Injection site AEs | | Birth + | BIrtht - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European rhCG Study Group, 2000 #58150 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy not defined Live birth: NR Multiples: NR Complications: Injection site AEs | rhCG | 26 | 71 | 97 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European rhCG Study Group, 2000 #58150 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy not defined Live birth: NR Multiples: NR Complications: Injection site AEs | uhCG | 21 | 72 | 93 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European rhCG Study Group, 2000 #58150 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy not defined Live birth: NR Multiples: NR Complications: Injection site AEs | Total | 47 | 143 | 190 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European rhCG Study Group, 2000 #58150 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy not defined Live birth: NR Multiples: NR Complications: Injection site AEs | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
European rhCG Study Group, 2000 #58150 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy not defined Live birth: NR Multiples: NR Complications: Injection site AEs | Rel risk | 1.19 | 0.72 | 1.96 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
3) Injection site AEs significantly less common with rhCG (0.24; 95% CI 0.11, 0.52)
European rLH Study Group, 2001 #5030 | Geographical location: 22 centers in 9 European countries Study dates: NR Size of population (no. of patients): 250 Number of cycles analyzed: NR Number of cycles per patient: Could not calculate Study type: RCT Interventions: rhLH: 5,000, 15,000, 30,000, or 15,000 + 10,000 IU (second injection administered 3 days after the first injection u-hCG: 5,000 IU | Age: Mean (SD): 31.8 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 39 [15.6%] Male factor: 45 [18.0%] Tubal factor: 152 [60.8%] Inclusion criteria: Premenopausal women between 18 and 39 yr old; BMI ≤ 32; menstrual cycle lasting between 21 and 35 days; FSH ≤12 IU/L, PRL ≤1040 mIU/L, TSH 0.3– 4.1 mIU/L; normal results in pretreatment hematology, clinical chemistry, or urinalysis parameters. Causes of infertility could include at least one of the following: tubal factor, mild endometriosis (American Fertility Society classification stage I or II), unexplained (with a history of at least 3 yr of infertility, and a postcoital test showing at least one forward progressive sperm per high power field), male factor (based on the investigator's judgment, but only if an oocyte fertilization rate of more than 50% had been observed during a previous IVF attempt after regular insemination, or if donor sperm was used), severe male factor (based on the investigator's judgment, but only if intracytoplasmic sperm injection was performed). Patients had to have both ovaries and have undergone no more than three previous assisted reproductive technology cycles, and have had no treatment with clomiphene citrate or gonadotropins for at least 1 month before screening, and a normal uterine cavity confirmed by hysteroscopy, or hysterosalpingography or a US scan performed within the past 5 yr. Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Pregnancy and clinical pregnancy, but not specifically defined. Live birth: Yes Complications: Minor, major AEs; OHSS, defined as at least one of the following clinical symptoms—abdominal distension, abdominal pain, nausea, vomiting, diarrhea or dyspnea lasting for at least 3 days after rhLH or u-hCG injection; diameter of the ovaries (maximum of the left and right ovaries) on days rhLH or u-hCG 6 and 7 greater than 5 cm; and ascites on days rhLH or u-hCG 6 and 7. In addition, the E2 level measured on the day of rhLH or u-hCG injection was used as a predictive factor: in each treatment group, patients were classified based on an E2 cut-off value of 3000 pg/mL as well as on the number of follicles observed just before administration of rhLH or u-hCG, with a cut-off value of 20 follicles. | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | rhLH | 24 | 105 | 129 | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | u-hCG | 31 | 90 | 121 | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | Total | 55 | 195 | 250 | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | Rel risk | 0.73 | 0.45 | 1.16 | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | 2) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | | Clin preg + | Clin preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | rhLH | 18 | 111 | 129 | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | u-hCG | 23 | 98 | 121 | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | Total | 41 | 209 | 250 | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | Rel risk | 0.73 | 0.42 | 1.29 | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | 3) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | | Live birth + | Live birth - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | rhLH | 14 | 115 | 129 | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | u-hCG | 16 | 105 | 121 | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | Total | 30 | 220 | 250 | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | Rel risk | 0.82 | 0.42 | 1.61 | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | 4) Adverse events | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | [underlined: Non-serious]: no statistically significant differences | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | [underlined: Serious]: “A total of 12 serious adverse events (3.6%) were recorded after rhLH or u-hCG administration in 10 patients (4.0%). Four of these serious adverse events occurred in the u-hCG treatment group: one patient was hospitalized for back pain, one for abdominal distension (OHSS), one to evacuate the remaining products of a missed abortion 6 weeks after u-hCG administration, and one for ectopic pregnancy. Six patients treated with rhLH experienced serious adverse events: one experienced retention of the fetal placenta (5,000 IU rhLH), one had abdominal pain (30,000 IU rhLH), one had abdominal pain and suspected ovarian torsion (15,000 1 10,000 IU rhLH), two patients were hospitalized for diarrhea (15,000 + 10,000 IU rhLH), and one patient had preeclampsia (15,000 + 10,000 IU rhLH). The most frequent nonserious adverse events reported after rhLH or u-hCG injection were abdominal enlargement (29 cases), abdominal pain (19 cases), injection site pain (14 cases), diarrhea (10 cases) and nausea (7 cases).” | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
European rLH Study Group, 2001 #5030 | | | | [underlined: OHSS:] “The proportion of patients presenting with moderate OHSS, independent of the number of follicles or E2 level was highly statistically related to treatment received (exact P = 0.0004, Cohchran-Armitage trend test), with the higher incidence in patients treated with 15,000 + 10,000 IU rhLH (12.0%) or 5,000 IU u-hCG (12.4%). In addition, the proportion of patients who did not present any of the three criteria for moderate OHSS was higher for the lower doses of rhLH than for the 15,000110,000 IU rhLH or 5,000 IU u-hCG treatments (48.7%, 28.2%, 23.1%, 20.0%, and 17.4%, respectively, for rhLH 5,000 IU, 15,000 IU, 30,000 IU, or 15,000110,000 IU rhLH and 5,000 IU u-hCG; exact p = 0.0003, Cochran-Armitage trend test).” | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Adequacy of randomization concealment: +
Note: OHSS by treatment group not reported.
Fabregues, Creus, Penarrubia, et al., 2006 #58160 | Geographical location: Barcelona, Spain Study dates: Nov 2003–Sep 2004 Size of population (no. of patients): 120 Number of cycles analyzed: 120 Number of cycles per patient: 1.0 Study type: RCT Interventions: Long protocol GnRH agonist, randomized to rFSH alone vs. rFSH + rLH beginning on day 6 of FSH | Age: Mean (SD): rFSH + rLH: 38.4 (1.4) rFSH: 38.2 (1.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 23 (19%) Endometriosis: 15 (12%) Male factor: 53 (45%) Tubal factor: 29 (24%) Inclusion criteria:; - 1^st^ cycle IVF/ICSI; - Age ≥ 35; - BMI 19–29; - Regular cycles; - Day 2–3 FSH < 12; - Hormonal therapy in previous 6 months; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Fabregues, Creus, Penarrubia, et al., 2006 #58160 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Fabregues, Creus, Penarrubia, et al., 2006 #58160 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | rFSH + rLH | 24 | 36 | 60 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Fabregues, Creus, Penarrubia, et al., 2006 #58160 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | rFSH | 25 | 35 | 60 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Fabregues, Creus, Penarrubia, et al., 2006 #58160 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Total | 49 | 71 | 120 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Fabregues, Creus, Penarrubia, et al., 2006 #58160 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Rel risk | 0.96 | 0.62 | 1.48
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | Geographical location: Barcelona, Spain Study dates: Sep 2002 – June 2003 Size of population (no. of patients): 150 Number of cycles analyzed: 150 Number of cycles per patient: 1 Study type: RCT Interventions: Group 1 (n = 75) pituitary desensitization was achieved by SC administration of triptorelin acetate (Decapeptyl 0.1 mg; Ipsen Pharma, Barcelona, Spain) (0.1 mg/d) started in the midluteal phase of the previous cycle and continued until the administration of hCG. Group 2 (n = 75 patients) the standard daily dose of triptorelin acetate was reduced to 0.05 mg once the ovarian arrest was confirmed and stimulation with recombinant FSH was commenced | Age: Mean (SEM): Reduced dose: 35.0 (0.3) Constant dose: 34.7 (0.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 19 (14%) Endometriosis: 26 (19%) Male factor: 57 (42%) Tubal factor: 35 (26%) Inclusion criteria: Regularly menstruating (menstrual cycles of 26–33 days) premenopausal, aged 26–40 years, body mass index (BMI) of 19.5–28.0 kg/m2, normal ovaries, no previous ovarian surgery, and no occult ovarian failure on the basis of their cycle day 2–3 FSH concentration of <12 IU/L (range 3.8–11 IU/L) (standard International Reference Preparation [IRP] 78/549) measured in the cycle preceding IVF/ICSI. No hormone therapy for at least 6 months preceding the study. Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Increasing serum concentrations of β-hCG after embryo transfer, and the subsequent demonstration of an intrauterine gestational sac by ultrasonography. Live birth: NR Multiples: Yes (twins) Complications: Miscarriage | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | Reduced dose | 28 | 41 | 69 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | Constant dose | 27 | 41 | 68 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | | 55 | 82 | 137 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | Rel risk | 1.02 | 0.68 | 1.54 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | 2) Twins: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | | Twins + | Twins - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | Reduced dose | 2 | 67 | 69 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | Constant dose | 3 | 65 | 68 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | | 5 | 132 | 137 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | Rel risk | 0.66 | 0.11 | 3.81 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | 3) Miscarriage: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | | SAb + | SAb - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | Reduced dose | 2 | 67 | 69 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | Constant dose | 3 | 65 | 68 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | | 5 | 132 | 137 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fabregues, Penarrubia, Creus, et al., 2005 #10170 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.66 | 0.11 | 3.81
Fatemi, Kolibianakis, Camus, et al., 2006 #51850 | Geographical location: Brussels, Belgium Study dates: Oct 2004–Oct 2005 Size of population (no. of patients): 201 Number of cycles analyzed: 201 Number of cycles per patient: 1.0 Study type: RCT Interventions: GnRH antagonist/rFSH COH, randomized to (a) 600 mg vaginal progesterone only, beginning 1 day after oocyte retrieval, until 7 weeks, vs (b) 600 mg progesterone + 4 mg/day E2 valerate over same time | Age: Mean (SD): P only: 32.1 (3.7); P + E2: 32.0 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 13% Endometriosis: 4% Male factor: 62% Tubal factor: 20% Inclusion criteria:; - ≤39 years; - BMI between 18 and 29 kg/m2; - presence of both varies; - basal levels of E2 (≤80 pg/ml), progesterone (≤1.6 ng/ml), FSH levels <10 IU/l at initiation of stimulation; - fewer than three prior cycles (agonist or antagonist cycles); Exclusion criteria:; - PCOS; - >Stage 2 endometriosis; - need for testicular sperm extraction; - PGD | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss - + hCG without development to 12 weeks | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Camus, et al., 2006 #51850 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss - + hCG without development to 12 weeks | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Camus, et al., 2006 #51850 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss - + hCG without development to 12 weeks | P + E2 | 30 | 71 | 101 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Camus, et al., 2006 #51850 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss - + hCG without development to 12 weeks | Prog only | 26 | 74 | 100 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Camus, et al., 2006 #51850 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss - + hCG without development to 12 weeks | | 56 | 145 | 201 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Camus, et al., 2006 #51850 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss - + hCG without development to 12 weeks | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Camus, et al., 2006 #51850 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss - + hCG without development to 12 weeks | Rel risk | 1.14 | 0.73 | 1.79 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Camus, et al., 2006 #51850 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss - + hCG without development to 12 weeks | 2) Early pregnancy loss: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Camus, et al., 2006 #51850 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss - + hCG without development to 12 weeks | | Loss + | Loss - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Camus, et al., 2006 #51850 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss - + hCG without development to 12 weeks | P + E2 | 9 | 30 | 39 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Camus, et al., 2006 #51850 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss - + hCG without development to 12 weeks | Prog only | 8 | 26 | 34 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Camus, et al., 2006 #51850 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss - + hCG without development to 12 weeks | | 17 | 56 | 73 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fatemi, Kolibianakis, Camus, et al., 2006 #51850 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss - + hCG without development to 12 weeks | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.98 | 0.43 | 2.26
Fluker, Grifo, Leader, et al., 2001 #65000 | Geographical location: Multicenter in New York, Georgia, New Jersey, Illinois, USA; British Columbia and Ontario, Canada Study dates: NR Size of population (no. of patients): 313 Number of cycles analyzed: 313 Number of cycles per patient: 1.0 Study type: RCT Interventions: GnRH agonist (leuprolide) vs GnRH antagonist (cetrorelix) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 51 (17%) Endometriosis: 42 (13%) Male factor: 42 (13%) Tubal factor: 84 (27%) Combined/other: 78 (25%) Inclusion criteria:; - Age 18–39; - Regular menses 24–35 days; - BMI ≥ 18 and ≤ 29 kg/m^2^; - For patients who had IVF without ICSI, partner or donor had to have normal semen characteristics according to WHO criteria (≥ 20 million/mL, > 50% motile, and ≥ 30% with normal morphology) or Kruger's criteria (> 4% with normal morphology); Exclusion criteria: Any clinically relevant hormone values outside the reference range during the early follicular phase (menstrual cycle day 2–7); specifically, FSH levels ≥ 10 IU/L or LH levels ≥ 10 IU/L | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | 1) Clinical pregnancy (all randomized): | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | Antag | 70 | 138 | 208 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | Agonist | 38 | 67 | 105 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | Total | 108 | 205 | 313 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 0.93 | 0.68 | 1.28 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | 2) Ongoing pregnancy (all randomized): | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | Antag | 61 | 147 | 208 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | Agonist | 36 | 69 | 105 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | Total | 97 | 216 | 313 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 0.86 | 0.61 | 1.20 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | 3) OHSS (all treated): | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | Antag | 12 | 187 | 199 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | Agonist | 2 | 97 | 99 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | Total | 14 | 284 | 298 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Fluker, Grifo, Leader, et al., 2001 #65000 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6 weeks (clinical) and 12 weeks (ongoing) Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 2.98 | 0.68 | 13.08 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
4) Lower FSH requirement with antagonist
Foong, Fleetham, O'Keane, et al., 2006 #51940 | Geographical location: Toronto and Calgary, Canada Study dates: 1997-2001 Size of population (no. of patients): 60 Number of cycles analyzed: 60 Number of cycles per patient: 1.0 Study type: RCT Interventions: IVF vs ICSI | Age: Mean (SD): IVF: 33.0 (3.6); ICSI: 33.7 (2.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 100% Inclusion criteria:; - Unexplained infertility; - female age 18–40 years, regular ovulatory menstrual cycles,; - day #3 E2<200 pmol/L,; - FSH<15 IU/L; - LH < 8 IU/L, normal thyroid stimulating hormone, ≥3 previous intrauterine insemination (IUI) cycles with clomiphene citrate or gonadotropins, normal uterine cavity, fallopian tubes and presence of both ovaries, normal ultrasound (US), and previous laparoscopy excluding stage III or IV endometriosis. All male partners had a normal semen analysis by WHO criteria; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + FHR on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Foong, Fleetham, O'Keane, et al., 2006 #51940 | | | Definition(s) of outcome(s): Pregnancy: + FHR on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Foong, Fleetham, O'Keane, et al., 2006 #51940 | | | Definition(s) of outcome(s): Pregnancy: + FHR on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | ICSI | 15 | 15 | 30 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Foong, Fleetham, O'Keane, et al., 2006 #51940 | | | Definition(s) of outcome(s): Pregnancy: + FHR on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | IVF | 15 | 15 | 30 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Foong, Fleetham, O'Keane, et al., 2006 #51940 | | | Definition(s) of outcome(s): Pregnancy: + FHR on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | 30 | 30 | 60 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Foong, Fleetham, O'Keane, et al., 2006 #51940 | | | Definition(s) of outcome(s): Pregnancy: + FHR on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Foong, Fleetham, O'Keane, et al., 2006 #51940 | | | Definition(s) of outcome(s): Pregnancy: + FHR on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.00 | 0.60 | 1.66 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Foong, Fleetham, O'Keane, et al., 2006 #51940 | | | Definition(s) of outcome(s): Pregnancy: + FHR on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Foong, Fleetham, O'Keane, et al., 2006 #51940 | | | Definition(s) of outcome(s): Pregnancy: + FHR on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Foong, Fleetham, O'Keane, et al., 2006 #51940 | | | Definition(s) of outcome(s): Pregnancy: + FHR on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | ICSI | 15 | 15 | 30 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Foong, Fleetham, O'Keane, et al., 2006 #51940 | | | Definition(s) of outcome(s): Pregnancy: + FHR on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | IVF | 14 | 16 | 30 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Foong, Fleetham, O'Keane, et al., 2006 #51940 | | | Definition(s) of outcome(s): Pregnancy: + FHR on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | 29 | 31 | 60 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Foong, Fleetham, O'Keane, et al., 2006 #51940 | | | Definition(s) of outcome(s): Pregnancy: + FHR on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 1.07 | 0.63 | 1.81
Friedler, Schachter, Strassburger, et al., 2007 #71050 | Geographical location: Tel Aviv, Israel Study dates: June 2004–Nov 2006 Size of population (no. of patients): 101 Number of cycles analyzed: 101 Number of cycles per patient: 1 Study type: RCT Interventions: All undergoing ICSI; embryo transfer with either hyaluronic acid enriched medium (EmbryoGlue®) or [human tubal fluid (HTF) medium with gentamicyn enriched with 20% serum substitute supplement, with no hyaluronic acid | Age: Mean (SD): Standard media: 31.7 (5.6) EmbryoGlue: 33.1 (5.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 43 years; - Failed to achieve an ongoing pregnancy after > 4 previous embryo transfers, during which 2–4 embryos were transferred each time, including at least one embryo with optimal cleavage rate and morphology (four cells on day 2 or eight cells on day 3, equal-sized blastomeres and 50% fragmentation); Exclusion criteria:; - Any systemic disease; - Body mass > 29 kg/m^2^; - Uterine malformation; - Evidence of low ovarian response in previous treatment cycles with < 4 oocytes retrieved; - Elevated baseline (day 3) FSH (> 12 IU/l); - Ultrasonographic evidence of hydrosalpinx; - Participation in any other clinical study | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: Study stopped after unplanned interim analysis - original sample size = 224 Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Friedler, Schachter, Strassburger, et al., 2007 #71050 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total
Friedler, Schachter, Strassburger, et al., 2007 #71050 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Hyaluronic acid | 18 | 33 | 51
Friedler, Schachter, Strassburger, et al., 2007 #71050 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | No HA | 5 | 45 | 50
Friedler, Schachter, Strassburger, et al., 2007 #71050 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Total | 23 | 78 | 101
Friedler, Schachter, Strassburger, et al., 2007 #71050 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Friedler, Schachter, Strassburger, et al., 2007 #71050 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Rel risk | 3.53 | 1.42 | 8.78
Friedler, Schachter, Strassburger, et al., 2007 #71050 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy:
Friedler, Schachter, Strassburger, et al., 2007 #71050 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total
Friedler, Schachter, Strassburger, et al., 2007 #71050 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Hyaluronic acid | 16 | 25 | 41
Friedler, Schachter, Strassburger, et al., 2007 #71050 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | No HA | 2 | 48 | 50
Friedler, Schachter, Strassburger, et al., 2007 #71050 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Total | 18 | 73 | 91
Friedler, Schachter, Strassburger, et al., 2007 #71050 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 9.76 | 2.38 | 39.99
Frydman, Howles, and Truong, 2000 #8600 | Geographical location: France Study dates: Dec 1995 – Dec 1996 Size of population: Grp 1: 139 Grp 2: 139 Number of cycles analyzed: 278 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: recombinant FSH for IVF/ICSI Grp 2: urinary FSH for IVF/ICSI | Age: Grp 1 Mean (SD): 31.4 (3.5) Grp 2: Mean (SD): 31.2 (4.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1: Unexplained infertility: 12 (8.6) Endometriosis: 2 (1.4) Male factor: 52 (37.4) Tubal factor: 60 (43.2) Grp 2: Unexplained infertility: 10 (7.2) Endometriosis: 2 (1.4) Male factor: 70 (50.4) Tubal factor: 39 (28.1) Inclusion criteria:; - Age 18–38; - Regular cycles 25–35 d; - Normal FSH, LH, PRL, T, and < 10 follicles per ovary; - 2 ovaries; - Normal uterus; - No more than 3 previous ART attempts; - No treatment with fertility drugs in last month; Exclusion criteria:; - Clinically significant systemic disease; - BMI > 30; - History of severe OHSS; - History of poor response to gonadotropins; - Male with azoospermia or leukospermia | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | 1) Ongoing pregnancy rate: | | | | Comments:; - 3 subjects included that had exclusion criteria: 1 age 39, 1 with > 3 previous attempts, and 1 with BMI > 30; - Underpowered to detect differences in adverse events; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | | Preg + | Preg - | Total
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | u-HFSH | 25 | 114 | 139
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | r-FSH | 25 | 114 | 139
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | Total | 50 | 228 | 278
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | | Value | Lower 95% CI | Upper 95% CI
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | Rel risk | 1.00 | 0.61 | 1.65
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | 2) Liveborn:
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | | Live birth + | Live birth - | Total
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | u-hFSH-HP | 35 | 104 | 139
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | r-hFSH | 36 | 103 | 139
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | Total | 71 | 207 | 278
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | | Value | Lower 95% CI | Upper 95% CI
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | Rel risk | 0.97 | 0.65 | 1.45
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | 4) Incidence of OHSS:
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | Grp 1: 7 (5%)
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | Grp 2: 3 (2.2%)
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | 5) SAB rate:
Frydman, Howles, and Truong, 2000 #8600 | | | Definition(s) of outcome(s): Pregnancy: Ongoing Live birth: Yes Multiples: Yes Complications: OHSS, SAB Primary endpoint: # of oocytes per treatment | Grp 1: 8 (5.7%)
Grp 2: 11 (7.9%)
Frydman, Madoux, Hesters, et al., 2006 #52000 | Geographical location: Clarmart, France Study dates: NR Size of population (no. of patients): 103 Number of cycles analyzed: 103 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to (a) no extra treatment of (b) assisted hatching with laser immediately prior to transfer | Age: Mean (SD): Control: 38.5; assisted hatching 39.0 Range: 37.0–42.3 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 9% Endometriosis: 17% Male factor: 43% Tubal factor: 31% Inclusion criteria:; (i) ≥37 years of age;; (ii) < 3 previous IVF-embryo transfer attempts and; (iii) having reached embryo transfer process; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Frydman, Madoux, Hesters, et al., 2006 #52000 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Frydman, Madoux, Hesters, et al., 2006 #52000 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Assisted hatching | 17 | 32 | 49 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Frydman, Madoux, Hesters, et al., 2006 #52000 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Control | 21 | 33 | 54 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Frydman, Madoux, Hesters, et al., 2006 #52000 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | 38 | 65 | 103 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Frydman, Madoux, Hesters, et al., 2006 #52000 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Frydman, Madoux, Hesters, et al., 2006 #52000 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.89 | 0.54 | 1.48 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Frydman, Madoux, Hesters, et al., 2006 #52000 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Frydman, Madoux, Hesters, et al., 2006 #52000 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Birth + | Birth - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Frydman, Madoux, Hesters, et al., 2006 #52000 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Assisted hatching | 11 | 38 | 49 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Frydman, Madoux, Hesters, et al., 2006 #52000 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Control | 16 | 38 | 54 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Frydman, Madoux, Hesters, et al., 2006 #52000 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | 27 | 76 | 103 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Frydman, Madoux, Hesters, et al., 2006 #52000 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.76 | 0.39 | 1.47
Fujimoto, Osuga, Fujiwara, et al., 2002 #230 | Geographical location: Tokyo and Saitama, Japan Study dates: 1/1998 – 12/2000 Size of population: 114 Number of cycles analyzed: 114 Number of cycles per patient: 1.00 Study type: RCT Interventions: Pts who failed 1^st^ cycle of IVF and had luteal phase E2 less than 100 pg/ml were randomized to the study. Luteal support with 25 mg of IM progesterone vs. 20 mg of IM progesterone and 3000 IU of hCG on day 1, 4, 7 after ET | Age: Mean (SD): P4: 35.2 (0.5) P4+hCG: 35.3 (0.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: h/o failed IVF and had luteal phase E2 less than 100 pg/ml Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + gestational sac on U/S 21d after ET Live birth: NR Multiples: NR Complications: OHSS | 1) Pregnancy rate: | | | | Comments: Randomization method not stated Quality assessment: Randomization method:- Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fujimoto, Osuga, Fujiwara, et al., 2002 #230 | | Age: Mean (SD): P4: 35.2 (0.5) P4+hCG: 35.3 (0.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: h/o failed IVF and had luteal phase E2 less than 100 pg/ml Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + gestational sac on U/S 21d after ET Live birth: NR Multiples: NR Complications: OHSS | | Preg + | Preg - | | Comments: Randomization method not stated Quality assessment: Randomization method:- Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fujimoto, Osuga, Fujiwara, et al., 2002 #230 | | Age: Mean (SD): P4: 35.2 (0.5) P4+hCG: 35.3 (0.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: h/o failed IVF and had luteal phase E2 less than 100 pg/ml Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + gestational sac on U/S 21d after ET Live birth: NR Multiples: NR Complications: OHSS | Prog + hCG | 20 | 43 | 63 | Comments: Randomization method not stated Quality assessment: Randomization method:- Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fujimoto, Osuga, Fujiwara, et al., 2002 #230 | | Age: Mean (SD): P4: 35.2 (0.5) P4+hCG: 35.3 (0.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: h/o failed IVF and had luteal phase E2 less than 100 pg/ml Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + gestational sac on U/S 21d after ET Live birth: NR Multiples: NR Complications: OHSS | Prog | 7 | 44 | 51 | Comments: Randomization method not stated Quality assessment: Randomization method:- Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fujimoto, Osuga, Fujiwara, et al., 2002 #230 | | Age: Mean (SD): P4: 35.2 (0.5) P4+hCG: 35.3 (0.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: h/o failed IVF and had luteal phase E2 less than 100 pg/ml Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + gestational sac on U/S 21d after ET Live birth: NR Multiples: NR Complications: OHSS | | 27 | 87 | 114 | Comments: Randomization method not stated Quality assessment: Randomization method:- Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fujimoto, Osuga, Fujiwara, et al., 2002 #230 | | Age: Mean (SD): P4: 35.2 (0.5) P4+hCG: 35.3 (0.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: h/o failed IVF and had luteal phase E2 less than 100 pg/ml Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + gestational sac on U/S 21d after ET Live birth: NR Multiples: NR Complications: OHSS | | | Lower 95% CI | Upper 95 % CI | Comments: Randomization method not stated Quality assessment: Randomization method:- Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Fujimoto, Osuga, Fujiwara, et al., 2002 #230 | | Age: Mean (SD): P4: 35.2 (0.5) P4+hCG: 35.3 (0.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: h/o failed IVF and had luteal phase E2 less than 100 pg/ml Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + gestational sac on U/S 21d after ET Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 2.31 | 1.06 | 5.03 | Comments: Randomization method not stated Quality assessment: Randomization method:- Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
2) 2 pts in P4+ hCG grp have OHHS
Garcia-Velasco, Isaza, Requena, et al., 2000 #6630 | Geographical location: Madrid, Spain Study dates: Nov 1, 1998 to Feb 28, 2000 Size of population (no. of patients): 70 Number of cycles analyzed: 70 Number of cycles per patient: 1 Study type: RCT Interventions: Non-stop protocol: Long GnRHa suppression with high doses of gonadotrophins. On days 1 and 2 of ovarian stimulation, three ampoules of HMG were administered together with five ampoules of FSH. On days 3, 4 and 5 of ovarian stimulation, two ampoules of HMG and three ampoules of FSH were administered. From day 6 onward, gonadotrophin dosage was estimated according to serum estradiol concentrations and transvaginal ovarian ultrasound scans. Stop protocol: GnRHa administration is stopped with the onset of menses, while gonadotrophin doses remained similar to the non-stop protocol | Age: Mean (SD): 34.2 (0.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 15 (21.4%) Male factor: 26 (37.1%) Tubal factor: 8 (11.4%) Other - combination male and female factors: 21 (30%) Inclusion criteria: At least one previous cancelled IVF attempt I which fewer than three follicles ≥ 18mm in diameter were obtained and basal FSH concentrations were < 12 IU/ml. Exclusion criteria: None | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Garcia-Velasco, Isaza, Requena, et al., 2000 #6630 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Garcia-Velasco, Isaza, Requena, et al., 2000 #6630 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Stop with menses | 5 | 31 | 36 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Garcia-Velasco, Isaza, Requena, et al., 2000 #6630 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Constant dose | 6 | 28 | 34 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Garcia-Velasco, Isaza, Requena, et al., 2000 #6630 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 11 | 59 | 70 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Garcia-Velasco, Isaza, Requena, et al., 2000 #6630 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.79 | 0.26 | 2.34
Gardner, Surrey, Minjarez, et al., 2004 #13610 | Geographical location: Englewood, CO Study dates: NR; 24-mo period Size of population: Grp 1: 23 Grp 2: 25 Number of cycles analyzed: 48 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: transfer of 1 blastocyst during IVF/ICSI Grp 2: transfer of 2 blastocyst during IVF/ICSI | Age: Grp 1: Mean (SEM): 33.5 (0.9) Range: 26–43 Grp 2: Mean (SEM): 34.2 (0.7) Range: 29–41 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Day 3 FSH < 10; - Day 3 estradiol < 80; - At least 10 follicles > 12 mm on day of hCG; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Cardiac activity on USD at least 4.5 wks after ET Live birth: NR Multiples: Yes Complications: NR | 1) Pregnancy rate: | | | | Comments:; - No information on diagnoses or previous IVF attempts; - Two blastocyst group had greater number of oocytes retrieved, fewer; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Gardner, Surrey, Minjarez, et al., 2004 #13610 | | | Definition(s) of outcome(s): Pregnancy: Cardiac activity on USD at least 4.5 wks after ET Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | Total
Gardner, Surrey, Minjarez, et al., 2004 #13610 | | | Definition(s) of outcome(s): Pregnancy: Cardiac activity on USD at least 4.5 wks after ET Live birth: NR Multiples: Yes Complications: NR | 1 blastocyst | 14 | 9 | 23
Gardner, Surrey, Minjarez, et al., 2004 #13610 | | | Definition(s) of outcome(s): Pregnancy: Cardiac activity on USD at least 4.5 wks after ET Live birth: NR Multiples: Yes Complications: NR | 2 blastocysts | 19 | 6 | 25
Gardner, Surrey, Minjarez, et al., 2004 #13610 | | | Definition(s) of outcome(s): Pregnancy: Cardiac activity on USD at least 4.5 wks after ET Live birth: NR Multiples: Yes Complications: NR | Total | 33 | 15 | 48
Gardner, Surrey, Minjarez, et al., 2004 #13610 | | | Definition(s) of outcome(s): Pregnancy: Cardiac activity on USD at least 4.5 wks after ET Live birth: NR Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Gardner, Surrey, Minjarez, et al., 2004 #13610 | | | Definition(s) of outcome(s): Pregnancy: Cardiac activity on USD at least 4.5 wks after ET Live birth: NR Multiples: Yes Complications: NR | Rel risk | 0.80 | 0.54 | 1.19
2) Multiples: 0 in single blastocyst, 9/19 in double
Geber, Moreira, de Paula, et al., 2007 #52040 | Geographical location: Belo Horizonte, Brazil Study dates: Jan–Dec 2001 Size of population (no. of patients): 244 Number of cycles analyzed: 244 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to vaginal progesterone after fertilization confirmed, continued for 13 days or 12 weeks gestation(a) 200 mg micronized P capsules 3×/day, or (b) micronized P in gel once daily | Age: Mean (SD): Capsules: 34.8 (5.6) Gel: 34.5 (5.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 90 (40.6%) Male factor: 106 (43.4%) Tubal factor: 39 (16.0%) Inclusion criteria: Day 3 FSH < 15 IU/L Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | Gel | 54 | 68 | 122 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | Capsule | 44 | 78 | 122 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | | 98 | 146 | 244 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | Rel risk | 1.23 | 0.90 | 1.67 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | 2) Early pregnancy loss: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | | Loss + | Loss - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | Gel | 8 | 46 | 54 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | Capsule | 7 | 37 | 44 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | | 15 | 83 | 98 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | Rel risk | 0.93 | 0.37 | 2.37 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | 3) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | Gel | 46 | 76 | 122 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | Capsule | 37 | 85 | 122 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | | 83 | 161 | 244 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Geber, Moreira, de Paula, et al., 2007 #52040 | | | Definition(s) of outcome(s): Pregnancy: + FHR 4 weeks after transfer Ongoing pregnancy: 20 weeks Live birth: NR Multiples: NR Complications: Early pregnancy loss | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.24 | 0.87 | 1.77
Gokmen, Ugur, Ekin, et al., 2001 #5190 | Geographical location: Ankara, Turkey Study dates: 1/1998 – 8/1998 Size of population: 250 (168 analyzed) Number of cycles analyzed: 168 Number of cycles per patient: 1.00 Study type: RCT Interventions: The study compared the prophylaxis usage of Intravenous albumin vs. hydroxyethyl starch for the prevention of OHHS The pt received either albumin, hydroxyethyl starch (HES), or did not receive anything (served as control) on the oocyte retrieval date. | Age: Mean (SD): Albumin: 29.6 (2.8) HES: 31.2 (3.7) Control: 32.3 (2.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: estradiol > 300 pg/ml or >20 follicles (>14 mm) on the day of hCG administration Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | 1) Pregnancy rate, HES vs. control: | | | | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Out + | Out - | Total | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | HES | 12 | 73 | 85 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Control | 10 | 73 | 83 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Total | 22 | 146 | 168 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Value | Lower 95% CI | Upper 95% CI | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Rel risk | 1.17 | 0.54 | 2.56 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | 2) Pregnancy rate, HES vs. albumin: | | | | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Out + | Out - | Total | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | HES | 12 | 73 | 85 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Albumin | 11 | 72 | 82 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Total | 23 | 145 | 168 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Value | Lower 95% CI | Upper 95% CI | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Rel risk | 1.07 | 0.50 | 2.28 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | 3) Pregnancy rate, albumin vs. control: | | | | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Out + | Out - | Total | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Albumin | 11 | 72 | 82 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Control | 10 | 73 | 83 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Total | 21 | 145 | 166 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Value | Lower 95% CI | Upper 95% CI | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Rel risk | 1.10 | 0.49 | 2.45 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | 4) Moderate OHHS, albumin vs. control: | | | | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Preg + | Preg - | | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Albumin | 4 | 81 | 85 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Control | 12 | 71 | 83 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | 16 | 152 | 168 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | | Lower 95% CI | Upper 95 % CI | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Rel risk | 0.33 | 0.11 | 0.97 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | 5) Moderate OHHS, HES vs. control: | | | | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Out + | Out - | Total | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | HES | 5 | 78 | 85 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Control | 12 | 71 | 83 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Total | 17 | 149 | 166 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Value | Lower 95% CI | Upper 95% CI | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Rel risk | 0.42 | 0.15 | 1.13 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | 6) Moderate OHHS, HES vs. albumin: | | | | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Out + | Out - | Total | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | HES | 5 | 78 | 85 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | albumin | 4 | 78 | 82 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Total | 9 | 156 | 165 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Value | Lower 95% CI | Upper 95% CI | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Rel risk | 1.23 | 0.34 | 4.44 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | 7) Severe OHHS, HES vs. albumin: | | | | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Out + | Out - | Total | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | HES | 0.5 | 85 | 85 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Albumin | 0.5 | 82 | 82 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Total | 1 | 167 | 168 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Value | Lower 95% CI | Upper 95% CI | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Rel risk | 0.96 | 0.02 | 48.07 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | 8) Severe OHHS, HES vs. control: | | | | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Out + | Out - | Total | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | HES | 0.5 | 78 | 85 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Control | 4 | 79 | 83 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Total | 4.5 | 157 | 161.5 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Value | Lower 95% CI | Upper 95% CI | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Rel risk | 0.13 | 0.01 | 2.46 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | 9) Severe OHHS, albumin vs. control: | | | | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Out + | Out - | Total | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Albumin | 0.5 | 82 | 82 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Control | 4 | 79 | 83 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Total | 4.5 | 161 | 165.5 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Value | Lower 95% CI | Upper 95% CI | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Rel risk | 0.13 | 0.01 | 2.34 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | 10) Overall OHHS rate, HES vs. albumin: | | | | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Out + | Out - | Total | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | HES | 5 | 78 | 85 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Albumin | 4 | 78 | 82 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Total | 9 | 156 | 165 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Value | Lower 95% CI | Upper 95% CI | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Rel risk | 1.23 | 0.34 | 4.44 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | 11) Overall OHHS rate, HES vs. control: | | | | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Out + | Out - | Total | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | HES | 5 | 85 | 85 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Control | 16 | 67 | 83 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Total | 21 | 152 | 173 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Value | Lower 95% CI | Upper 95% CI | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Rel risk | 0.29 | 0.11 | 0.75 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | 12) Overall OHHS rate, albumin vs. control: | | | | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Out + | Out - | Total | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Albumin | 4 | 78 | 82 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Control | 16 | 67 | 83 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | Total | 20 | 145 | 165 | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Gokmen, Ugur, Ekin, et al., 2001 #5190 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHHS (diagnosed using Schenker and Weinstein criteria) | | Value | Lower 95% CI | Upper 95% CI | Comments: Sample size/analysis not corrected for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.25 | 0.09 | 0.72
Gomez-Palomares, Acevedo-Martin, Andres, et al., 2005 #39220 | Geographical location: Madrid, Spain Study dates: NR Size of population: Grp 1: HMG 58 Grp 2: rLH 36 Number of cycles analyzed: 94 Number of cycles per patient: 1.00 Study type: RCT Interventions: Compare the usage of rFSH+hMG vs. rFSH+LH for the first 5 days of controlled ovarian stimulation in women older than 38 yo. Both grps received only rFSH after 5 days of combined therapy Treatment detailed Control: rFSH 225 IU + 150 IU of hMH (equal to 75 IU of FSH and 75 IU of LH) Study grp: rFSH 300 IU + 75 IU of rLH This is a GnRH agonist long protocol. | Age: Mean (SD): Grp 1: 39 [0.7] Grp 2: 38.8 [1.5] Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1 Unexplained infertility: NR Endometriosis: 4 [6.9] Male factor: 23 [39.7] Tubal factor: 15 [25.9] PCOS: 0 Insemination failure: 16 [27.6] Grp 2 Unexplained infertility: NR Endometriosis: 3 [8.3] Male factor: 14 [38.9] Tubal factor: 11 [30.6] PCOS: 0 Insemination failure: 8 [22.2] Inclusion criteria: Age 38–40 Nl basal FSH, LH, E2. Regular cycle 25–32 d. BMI 19–25 Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: clinical - positive fetal heart beat Live birth: NR Multiples: NR Complications: SAB rate | 1) Clinical pg rate grp 1 vs 2: | | | | Comments:; - Secondary change in enrollment led to differences in numbers in 2 grps; - Randomization not clearly described-inequality between groups quite large; Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: NR Adequacy of randomization concealment: no
Gomez-Palomares, Acevedo-Martin, Andres, et al., 2005 #39220 | | | Definition(s) of outcome(s): Pregnancy: clinical - positive fetal heart beat Live birth: NR Multiples: NR Complications: SAB rate | | pg pos | Pg neg | Total
Gomez-Palomares, Acevedo-Martin, Andres, et al., 2005 #39220 | | | Definition(s) of outcome(s): Pregnancy: clinical - positive fetal heart beat Live birth: NR Multiples: NR Complications: SAB rate | HMG | 12 | 46 | 58
Gomez-Palomares, Acevedo-Martin, Andres, et al., 2005 #39220 | | | Definition(s) of outcome(s): Pregnancy: clinical - positive fetal heart beat Live birth: NR Multiples: NR Complications: SAB rate | rLH | 16 | 20 | 36
Gomez-Palomares, Acevedo-Martin, Andres, et al., 2005 #39220 | | | Definition(s) of outcome(s): Pregnancy: clinical - positive fetal heart beat Live birth: NR Multiples: NR Complications: SAB rate | Total | 28 | 66 | 94
Gomez-Palomares, Acevedo-Martin, Andres, et al., 2005 #39220 | | | Definition(s) of outcome(s): Pregnancy: clinical - positive fetal heart beat Live birth: NR Multiples: NR Complications: SAB rate | | Value | Lower 95% CI | Upper 95% CI
Gomez-Palomares, Acevedo-Martin, Andres, et al., 2005 #39220 | | | Definition(s) of outcome(s): Pregnancy: clinical - positive fetal heart beat Live birth: NR Multiples: NR Complications: SAB rate | Rel risk | 0.47 | 0.25 | 0.87
Gomez-Palomares, Acevedo-Martin, Andres, et al., 2005 #39220 | | | Definition(s) of outcome(s): Pregnancy: clinical - positive fetal heart beat Live birth: NR Multiples: NR Complications: SAB rate | 2) SAB rate:
Gomez-Palomares, Acevedo-Martin, Andres, et al., 2005 #39220 | | | Definition(s) of outcome(s): Pregnancy: clinical - positive fetal heart beat Live birth: NR Multiples: NR Complications: SAB rate | | SAB | No SAB | Total
Gomez-Palomares, Acevedo-Martin, Andres, et al., 2005 #39220 | | | Definition(s) of outcome(s): Pregnancy: clinical - positive fetal heart beat Live birth: NR Multiples: NR Complications: SAB rate | Grp 1 | 2 | 12 | 14
Gomez-Palomares, Acevedo-Martin, Andres, et al., 2005 #39220 | | | Definition(s) of outcome(s): Pregnancy: clinical - positive fetal heart beat Live birth: NR Multiples: NR Complications: SAB rate | Grp 2 | 2 | 14 | 16
Gomez-Palomares, Acevedo-Martin, Andres, et al., 2005 #39220 | | | Definition(s) of outcome(s): Pregnancy: clinical - positive fetal heart beat Live birth: NR Multiples: NR Complications: SAB rate | Total | 4 | 26 | 30
Gomez-Palomares, Acevedo-Martin, Andres, et al., 2005 #39220 | | | Definition(s) of outcome(s): Pregnancy: clinical - positive fetal heart beat Live birth: NR Multiples: NR Complications: SAB rate | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.14 | 0.18 | 7.08
Gordon, Harrison, Fawzy, et al., 2001 #58250 | Geographical location: Dublin, Ireland Study dates: NR Size of population (no. of patients): 128 Number of cycles analyzed: 128 Number of cycles per patient: 1.0 Study type: RCT Interventions: 4 different gonadotropin regimens with varying levels of LH:; a) rFSH alone; b) uFSH (< 1 IU LH); c) hMG with 25 IU LH; d) hMG with 75 IU LH; All FSH doses 75 IU | Age: Mean: 32.5 Range: 31–36 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 65 (51%) Endometriosis: 21 (16%) Tubal factor: 36 (28%) Other: Anovulation: 6 (5%) Inclusion criteria:; - Age 20–39; - Weight 80–130% ideal body weight; - Normal cycles; - 2 year history of infertility; - 1^st^ IVF cycle; Exclusion criteria:; - PCOS; - Male factor | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | 1) Pregnancy, rFSH alone vs. uFSH: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | uFSH | 4 | 26 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | rFSH | 11 | 28 | 39 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | Total | 15 | 54 | 69 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.47 | 0.17 | 1.34 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | 2) Pregnancy, rFSH alone vs. FSH + 25 IU LH: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | rFSH + 25 IU LH | 8 | 22 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | rFSH | 11 | 28 | 39 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | Total | 19 | 50 | 69 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.95 | 0.43 | 2.06 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | 3) Pregnancy, rFSH alone vs. FSH + 75 IU LH: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | rFSH + 75 IU LH | 11 | 18 | 29 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | rFSH | 11 | 28 | 39 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | Total | 22 | 46 | 68 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.34 | 0.68 | 2.66 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | 4) Live birth, rFSH alone vs. uFSH: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | uFSH | 2 | 28 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | rFSH | 9 | 30 | 39 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | Total | 11 | 58 | 69 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.29 | 0.07 | 1.24 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | 5) Live birth, rFSH alone vs. FSH + 25 IU LH: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | rFSH + 25 IU LH | 6 | 24 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | rFSH | 9 | 30 | 39 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | Total | 15 | 54 | 69 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.87 | 0.35 | 2.17 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | 6) Live birth, rFSH alone vs. FSH + 75 IU LH: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | rFSH + 75 IU LH | 9 | 21 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | rFSH | 9 | 30 | 39 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | Total | 18 | 51 | 69 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Gordon, Harrison, Fawzy, et al., 2001 #58250 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 7 weeks Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.30 | 0.59 | 2.87
Goswami, Das, Chattopadhyay, et al., 2004 #11140 | Geographical location: West Bengal, India Study dates: July 2002–Aug 2003 Size of population: 48 recruited with 10 excluded Grp 1: 13 Grp 2: 25 Number of cycles analyzed: 38 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: 2.5 mg Letrozole plus 75IU rFSH on days 3 and 8 Grp 2: Luteal phase down-regulation with Lupron followed by rFSH At doses of 300–450IU | Age: Mean (SD): Grp 1: 38.5 (1.7) Grp 2: 39.1 (1.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age > 35; - Failed 1–3 IVF attempts due to “poor ovarian response”; - 1–3 no treatment cycles between last IVF and study cycle; Exclusion criteria:; - Severe endometriosis (n = 4); - History of pelvic surgery (n = 3); - FSH > 12 (n = 1); - Refusal to participate (n = 2) | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments:; - Low power; - No embryo status reported; Quality assessment: Randomization method: + Blinding: single to investigator Dropout rate < 20%: + Adequacy of randomization concealment: +
Goswami, Das, Chattopadhyay, et al., 2004 #11140 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments:; - Low power; - No embryo status reported; Quality assessment: Randomization method: + Blinding: single to investigator Dropout rate < 20%: + Adequacy of randomization concealment: +
Goswami, Das, Chattopadhyay, et al., 2004 #11140 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | rFSH + letrozole | 3 | 10 | 13 | Comments:; - Low power; - No embryo status reported; Quality assessment: Randomization method: + Blinding: single to investigator Dropout rate < 20%: + Adequacy of randomization concealment: +
Goswami, Das, Chattopadhyay, et al., 2004 #11140 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | rFSH | 6 | 19 | 25 | Comments:; - Low power; - No embryo status reported; Quality assessment: Randomization method: + Blinding: single to investigator Dropout rate < 20%: + Adequacy of randomization concealment: +
Goswami, Das, Chattopadhyay, et al., 2004 #11140 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | Total | 9 | 29 | 38 | Comments:; - Low power; - No embryo status reported; Quality assessment: Randomization method: + Blinding: single to investigator Dropout rate < 20%: + Adequacy of randomization concealment: +
Goswami, Das, Chattopadhyay, et al., 2004 #11140 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments:; - Low power; - No embryo status reported; Quality assessment: Randomization method: + Blinding: single to investigator Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.96 | 0.29 | 3.23
Goverde, McDonnell, Vermeiden, et al., 2000 #58260 | Geographical location: Amsterdam, The Netherlands Study dates: NR Size of population (no. of patients): 258 Number of cycles analyzed: 943 Number of cycles per patient: 3.6 Study type: RCT Interventions:; (a) IUI alone (spontaneous cycle, timed by urinary LH); (b) IUI with mild stimulation (gonadotropin dosed to reach 2–3 dominant follicles, hCG final maturation); (c) IVF | Age: Mean (SD): IUI alone: 31.6 (3.7) IUI + stimulation: 31.7 (3.9) IVF: 32.1 (4.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 181 (70%) Male factor: 77 (30%) Inclusion criteria: Idiopathic infertility for 3 years, or male infertility for 1 year Exclusion criteria:; - Cycle disorders; - Untreated endometriosis (American Fertility Society criteria grade 2–4); - Bilateral occluded tubes - Semen sample yielding < 1 million progressively motile spermatozoa after processing by Percoll 40/80 gradient centrifugation; - > 20% of spermatozoa carrying antibodies as tested with an immunobead test after Percoll processing; - > 50% of spermatozoa with no acrosome | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | 1) Cumulative pregnancy, IUI vs. IUI with mild stimulation: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Goverde, McDonnell, Vermeiden, et al., 2000 #58260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Goverde, McDonnell, Vermeiden, et al., 2000 #58260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | IUI + stim | 31 | 54 | 85 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Goverde, McDonnell, Vermeiden, et al., 2000 #58260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | IUI | 25 | 61 | 86 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Goverde, McDonnell, Vermeiden, et al., 2000 #58260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | Total | 56 | 115 | 171 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Goverde, McDonnell, Vermeiden, et al., 2000 #58260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Goverde, McDonnell, Vermeiden, et al., 2000 #58260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | Rel risk | 1.25 | 0.81 | 1.93 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Goverde, McDonnell, Vermeiden, et al., 2000 #58260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | 2) Cumulative pregnancy, IUI vs. IVF: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Goverde, McDonnell, Vermeiden, et al., 2000 #58260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Goverde, McDonnell, Vermeiden, et al., 2000 #58260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | IVF | 33 | 54 | 87 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Goverde, McDonnell, Vermeiden, et al., 2000 #58260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | IUI | 25 | 61 | 86 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Goverde, McDonnell, Vermeiden, et al., 2000 #58260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | Total | 58 | 115 | 173 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Goverde, McDonnell, Vermeiden, et al., 2000 #58260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Goverde, McDonnell, Vermeiden, et al., 2000 #58260 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: NR | Rel risk | 1.30 | 0.85 | 2.00 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
3) Per cycle rate higher with IVF, but greater dropout rate in those who failed to conceive. Multiples higher in IUI with stimulation and IVF compared to IUI alone.
Greco, Polonio-Balbi, Ferrero, et al., 2005 #39210 | Geographical location: Rome, Italy; Granada, Spain Study dates: May 2000–Feb 2003 Size of population: Grp 1 used drug injector - 148 Grp 2 used syringe - 152 Number of cycles analyzed: 300 Number of cycles per patient: 1.00 Study type: RCT Interventions: Women undergoing IVF/ICSI randomized to administer rFSH by automated injector vs syringe | Age: Mean (SD): Grp 1: 30.5 [3.9] Grp 2: 30.9 [3.6] Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1 Unexplained infertility: 22 [15] Endometriosis: 0 Male factor: 100 [68] Tubal factor: 19 [13] PCOS: 0 Other: 6 [4] Grp 2 Unexplained infertility: 21 [14] Endometriosis: 0 Male factor: 106 [70]] Tubal factor: 17 [11] PCOS: 0 Other: 8 [5] Inclusion criteria: Age < 36 BMI 18–29 2 ovaries basal FSH <12 Absence of PCOS or endometriosis by USD Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pg rate grp 1 vs 2: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: NR
Greco, Polonio-Balbi, Ferrero, et al., 2005 #39210 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | pg pos | pg neg | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: NR
Greco, Polonio-Balbi, Ferrero, et al., 2005 #39210 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Injector | 66 | 82 | 148 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: NR
Greco, Polonio-Balbi, Ferrero, et al., 2005 #39210 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Syringe | 58 | 94 | 152 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: NR
Greco, Polonio-Balbi, Ferrero, et al., 2005 #39210 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 124 | 176 | 300 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: NR
Greco, Polonio-Balbi, Ferrero, et al., 2005 #39210 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: NR
Rel risk | 1.17 | 0.89 | 1.53
Griesinger, Schultze-Mosgau, Dafopoulos, et al., 2005 #42140 | Geographical location: Luebeck, Germany Study dates: 6/03 – 12/03 Size of population: 127 Number of cycles analyzed: 127 Number of cycles per patient: 1.0 Study type: RCT Interventions: The study compared the usage of rFSH alone vs rFSH+rLH for ovulation induction in GnRH antagonist cycle. Both grps started the gonadotropins (either rFSH alone or rFSH and rLH) on cycle day 2. This is an IVF cycle!! | Age: Mean (SD): rFSH: 30.5 (4.2) rFSH+rLH: 30.3 (4.7) Median: NR Range: 20–39 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: See other Endometriosis: See other Male factor only: rFSH: 32 (49.2) rFSH+rLH: 34 (54.8) Tubal factor only: rFSH: 7 (10.8) rFSH+rLH: 9 (14.5) PCOS: 0 Other (specify): Idiopathic/endometriosis: rFSH: 9 (13.8) rFSH+rLH: 5 (8.0) Male factor and endometriosis: rFSH: 2 (3.0) rFSH+rLH: 2 (3.2) Inclusion criteria: Inclusion criteria:; - Age 20–39; - BMI 18–35; - Regular menstrual cycle (ranging 24d–35d); - Intra-individual cycle variability of ≤3d; - Use of fresh as well as frozen thawed sperm retrieved by testicular biopsy.; Exclusion criteria:; - > 3 failed ART; - Previous poor response to gonadotropin stimulation defined as< 3 preovulatory follicles.; - History of ovarian hyperstimulation syndrome grade II–III; - PCOS; - Other endocrine disorder; - No natural luteal phase prior to treatment cycle; - Abnormal uterine cavity as evaluated by u/s.; - Presence of a clinically significant systemic disease | Definition(s) of outcome(s): Pregnancy: Biochemical pregnancy: hCG ≥ 10 mIU/ml 14d after embryo transfer Clinical pregnancy: An ongoing pregnancy at 12 wks of gestation Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Griesinger, Schultze-Mosgau, Dafopoulos, et al., 2005 #42140 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Griesinger, Schultze-Mosgau, Dafopoulos, et al., 2005 #42140 | | | | Study drug | 8 | 54 | 62 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Griesinger, Schultze-Mosgau, Dafopoulos, et al., 2005 #42140 | | | | Control | 12 | 53 | 65 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Griesinger, Schultze-Mosgau, Dafopoulos, et al., 2005 #42140 | | | | | 20 | 107 | 127 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Griesinger, Schultze-Mosgau, Dafopoulos, et al., 2005 #42140 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.70 | 0.31 | 1.59
Hassan, Azab, Rahman, et al., 2001 #3810 | Geographical location: Alexandria, Egypt Study dates: NR Size of population (no. of patients): 88 Number of cycles analyzed: 88 Number of cycles per patient: 1.0 Study type: RCT Interventions: ICSI, agonist down regulation, immature oocytes retrieved (in vitro maturation), randomized to no extra treatment or hGH 4 IU daily during stimulation | Age: Mean (SD): GH: 32.4 (0.4) No GH: 31.7 (0.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 88 (100%) Inclusion criteria: Undergoing ICSI for male infertility Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy (based on reported percentages): | | | | Comments: Randomization method not specified Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Hassan, Azab, Rahman, et al., 2001 #3810 | | Age: Mean (SD): GH: 32.4 (0.4) No GH: 31.7 (0.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 88 (100%) Inclusion criteria: Undergoing ICSI for male infertility Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: Randomization method not specified Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Hassan, Azab, Rahman, et al., 2001 #3810 | | Age: Mean (SD): GH: 32.4 (0.4) No GH: 31.7 (0.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 88 (100%) Inclusion criteria: Undergoing ICSI for male infertility Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | hGH | 14 | 30 | 44 | Comments: Randomization method not specified Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Hassan, Azab, Rahman, et al., 2001 #3810 | | Age: Mean (SD): GH: 32.4 (0.4) No GH: 31.7 (0.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 88 (100%) Inclusion criteria: Undergoing ICSI for male infertility Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | No GH | 11 | 33 | 44 | Comments: Randomization method not specified Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Hassan, Azab, Rahman, et al., 2001 #3810 | | Age: Mean (SD): GH: 32.4 (0.4) No GH: 31.7 (0.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 88 (100%) Inclusion criteria: Undergoing ICSI for male infertility Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 25 | 63 | 88 | Comments: Randomization method not specified Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Hassan, Azab, Rahman, et al., 2001 #3810 | | Age: Mean (SD): GH: 32.4 (0.4) No GH: 31.7 (0.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 88 (100%) Inclusion criteria: Undergoing ICSI for male infertility Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Randomization method not specified Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 1.27 | 0.65 | 2.49
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | Geographical location: Rotterdam and Utrecht, Netherlands Study dates: Feb 2002 to Mar 2004 Size of population (no. of patients): 404 Number of cycles analyzed: 769 Number of cycles per patient: 1.9 Study type: RCT Interventions: Mild: mild ovarian stimulation with gonadotropin-releasing hormone [GnRH] antagonist cotreatment combined with single embryo transfer Standard: Stimulation with a GnRH agonist long protocol and transfer of two embryos. | Age: Mean (SD): 32.8 (3.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 91 (22%) Endometriosis: 0 (0%) Male factor: 221 (55%) Tubal factor: 67 (17%) PCOS: 0 (0%) Other (specify): 26 (7%) Inclusion criteria: No previous IVF treatment or had borne a healthy child after previous IVF treatment, were aged younger than 38 years, and had a menstrual cycle length of 25–35 days and a body-mass index of 18–28 kg/m^2^ Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | 1) Continuing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | | Clinical pregnancy | No clinical pregnancy | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | Mild | 96 | 109 | 205 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | Standard | 102 | 97 | 199 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | Total | 198 | 206 | 404 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 0.91 | 0.75 | 1.11 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | | Live birth | No live birth | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | Mild | 70 | 135 | 205 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | Standard | 78 | 121 | 199 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | Total | 148 | 256 | 404 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 0.87 | 0.67 | 1.13 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | 3) Multiple births: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen Eijkemans, De Klerk, et al., 2007 #52530 | | | Definition(s) of outcome(s): Pregnancy: Continuing pregnancy: Positive heartbeat on ultrasound at 10 weeks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | Mild 0.5% (CI 0 to 2.7%) | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Standard 13.1% (CI 8.7 to 18.6%)
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | Geographical location: Utrecht and Arnhem, Netherlands Study dates: Oct 2001 to Dec 2003 Size of population (no. of patients): 45 Number of cycles analyzed: 112 Number of cycles per patient: 2.5 Study type: RCT Interventions: DET: double embryo transfer over a maximum of 4 cycles TET: triple embryo transfer over a maximum of 3 cycles | Age: Mean (SD): 41 (2.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: (41%) Male factor: 31% Tubal factor: 22% Other: 4.4% Inclusion criteria: 38 years and older and an indication for an IVF or IVF/ICSI treatment either for the first time or after a previous IVF or IVF/ICSI childbirth Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | | Clinical preg + | Clinical preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | DET | 18 | 5 | 23 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | TET | 11 | 11 | 22 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | Total | 29 | 16 | 45 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | Rel risk | 1.57 | 0.98 | 2.50 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | 2) Live term birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | | Live term birth | No live term birth | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | DET | 10 | 13 | 23 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | TET | 8 | 14 | 22 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | Total | 18 | 27 | 45 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | Rel risk | 1.20 | 0.58 | 2.46 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | 3) Multiple pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | | Multiple + | Multiple - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | DET | 0 | 10 | 10 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | TET | 3 | 5 | 8 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | Total | 3 | 15 | 18 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Heijnen, Klinkert, Schmoutziguer, et al., 2006 #52550 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy Live birth: Term: >37 weeks Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.12 | 0.01 | 1.98
Hohmann, Macklon, and Fauser, 2003 #17550 | Geographical location: Rotterdam, Netherlands Study dates: Nov 1999–May 2003 Size of population (no. of patients): 169—13 did not start IVF, 14 excluded for violation of inclusion criteria or protocol—4 pregnancies in this group 142 analyzed Allocation of subjects excluded from analysis not described Number of cycles analyzed: 142 Number of cycles per patient: 1.0 Study type: RCT Interventions:; a) Long protocol GnRH agonist (triptorelin) down-regulation for COH for IVF/ICSI, with fixed daily dose of 150 IU rFSH only; b) rFSH + 0.25 microgram/day GnRH antagonist cetrorelix, beginning on day 2; c) rFSH + 0.25 microgram/day GnRH antagonist cetrorelix, beginning on day 5; All continued through day of hCG administration | Age: Median: 33 for all 3 groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; 1) age between 20–38 yr;; 2) body mass index (body weight divided by the square of body height) between 19–29kg/m2;; 3) history of regular menstrual cycles, ranging from 25–35 d;; 4) no relevant systemic disease, severe endometriosis, or uterine and ovarian abnormalities;; 5) no more than three previous IVF cycles; and; 6) no previous IVF cycle with a poor response or ovarian hyperstimulation syndrome; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | 1) Ongoing pregnancy, GnRH antagonist day 2 start vs GnRH agonist long protocol: | | | | Comments:; - Power based on differences in E2 levels; - No adjustment for multiple comparisons; - Unable to calculate intention-to-treat rates from presented data; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - (~15%, but allocation of dropouts/exclusions not included Adequacy of randomization concealment: +
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | Day 2 | 10 | 38 | 48
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | GnRH agonist | 10 | 35 | 45
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | | 20 | 73 | 93
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.94 | 0.43 | 2.04
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy, GnRH antagonist day5 start vs GnRH agonist long protocol:
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | Day 5 | 10 | 39 | 49
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | Control | 10 | 35 | 45
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | | 20 | 74 | 94
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.92 | 0.42 | 2.00
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | 3) Ongoing pregnancy, GnRH antagonist day5 start vs GnRH antagonist day 2 start:
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | Day 5 | 10 | 39 | 49
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | Day 2 | 10 | 38 | 48
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | | 20 | 77 | 97
Hohmann, Macklon, and Fauser, 2003 #17550 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy: fetal heart rate at 12 weeks Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 0.98 | 0.45 | 2.14
Hoomans, Mulder, and Asian Purgeon Study Group, 2002 #610 and Ng, Yeung, and Ho, 2000 #6200 | Geographical location: Multiple sites in Hong Kong, Thailand, Singapore, and India Study dates: Dec 1997–July 1999 Size of population (no. of patients): 230 Number of cycles analyzed: 230 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - GnRH agonist down regulation; - Randomized to 1 of 2 starting doses of rFSH (100 IU vs 200 IU) | Age: Mean (SD): 100 IU: 31.6 (3.6); 200 IU 32.1 (3.8) Race/ethnicity (n [%]): 100% Asian Diagnoses (n [%]): Unexplained infertility: 31% Endometriosis: 24% Male factor: 58% Tubal factor: 68% Inclusion criteria:; - Age 18–39; - BMI 18–29; - Candidate for IVF/ICSI; - Regular menses; Exclusion criteria:; - Infertility caused by endocrine abnormalities such as hyperprolactinemia, polycystic ovarian syndrome and absence of ovarian function; - previous assisted reproduction in which fewer than three oocytes were retrieved.; - previous hospitalization due to severe ovarian hyperstimulation syndrome,; - chronic cardiovascular, hepatic, renal, or pulmonary disease; - history of (within 12 months) or currently indulged in abuse of alcohol or drugs; - used investigational drugs within 3 months before screening. | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Hoomans, Mulder, and Asian Purgeon Study Group, 2002 #610 and Ng, Yeung, and Ho, 2000 #6200 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Hoomans, Mulder, and Asian Purgeon Study Group, 2002 #610 and Ng, Yeung, and Ho, 2000 #6200 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 100 IU | 33 | 130 | 163 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Hoomans, Mulder, and Asian Purgeon Study Group, 2002 #610 and Ng, Yeung, and Ho, 2000 #6200 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 200IU | 30 | 136 | 166 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Hoomans, Mulder, and Asian Purgeon Study Group, 2002 #610 and Ng, Yeung, and Ho, 2000 #6200 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 63 | 266 | 329 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Hoomans, Mulder, and Asian Purgeon Study Group, 2002 #610 and Ng, Yeung, and Ho, 2000 #6200 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Hoomans, Mulder, and Asian Purgeon Study Group, 2002 #610 and Ng, Yeung, and Ho, 2000 #6200 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.12 | 0.72 | 1.75 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Hoomans, Mulder, and Asian Purgeon Study Group, 2002 #610 and Ng, Yeung, and Ho, 2000 #6200 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Hoomans, Mulder, and Asian Purgeon Study Group, 2002 #610 and Ng, Yeung, and Ho, 2000 #6200 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Hoomans, Mulder, and Asian Purgeon Study Group, 2002 #610 and Ng, Yeung, and Ho, 2000 #6200 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 100 IU | 27 | 136 | 163 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Hoomans, Mulder, and Asian Purgeon Study Group, 2002 #610 and Ng, Yeung, and Ho, 2000 #6200 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 200 IU | 25 | 141 | 166 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Hoomans, Mulder, and Asian Purgeon Study Group, 2002 #610 and Ng, Yeung, and Ho, 2000 #6200 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 52 | 277 | 329 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Hoomans, Mulder, and Asian Purgeon Study Group, 2002 #610 and Ng, Yeung, and Ho, 2000 #6200 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
Hoomans, Mulder, and Asian Purgeon Study Group, 2002 #610 and Ng, Yeung, and Ho, 2000 #6200 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.10 | 0.67 | 1.81 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: -
3) More oocytes retrieved in 200 IU group:
Hreinsson, Rosenlund, Friden, et al., 2003 #15400 | Geographical location: Stockholm, Sweden Study dates: NR Size of population (no. of patients): 73 Number of cycles analyzed: 73 Number of cycles per patient: 1.0 Study type: RCT Interventions: In vitro oocyte maturation with (a) recombinant hCG or (b) recombinant LH | Age: Mean (SD): hCG: 31.3 (3.8) LH: 31.9 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 24 (33%) Male factor: 25 (34%) Tubal factor: 6 (8%) Other: Anovulation 18 (25%) Inclusion criteria:; - Age 20–40; - Indication for IVF/ICSI; Exclusion criteria: Male factor requiring testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 6 weeks Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy (not ITT - only data on completed cycles reported): | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hreinsson, Rosenlund, Friden, et al., 2003 #15400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 6 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hreinsson, Rosenlund, Friden, et al., 2003 #15400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 6 weeks Live birth: NR Multiples: NR Complications: NR | rLH | 1 | 36 | 37 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hreinsson, Rosenlund, Friden, et al., 2003 #15400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 6 weeks Live birth: NR Multiples: NR Complications: NR | rhCG | 3 | 33 | 36 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hreinsson, Rosenlund, Friden, et al., 2003 #15400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 6 weeks Live birth: NR Multiples: NR Complications: NR | Total | 4 | 69 | 73 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hreinsson, Rosenlund, Friden, et al., 2003 #15400 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 6 weeks Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Rel risk | 0.32 | 0.04 | 2.97
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | Geographical location: Stockholm, Sweden Study dates: NR Size of population (no. of patients): 144 Number of cycles analyzed: 144 Number of cycles per patient: 1.0 Study type: RCT Interventions: Embryo transfer on (a) day 2–3 vs (b) day 3–5 1–2 embryos transferred | Age: Mean (SD): Day 2–3: 33.1; Day 5–6:32.1 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 30 (20.8%) Endometriosis: 16 (11.1%) Male factor: 45 (31.3%) Tubal factor: 29 (20.1%) PCOS: 12 (8.0%) Combined: 20 (13.9%) Inclusion criteria: ≥ 6 follicles Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | 1) Clinical pregnancy: | | | | Comments:; - Study stopped due to change in national policy; - Relatively large imbalance between arms; - Greater proportion tubal factor in Day 2–3 group (26% vs 13%); Quality assessment: Randomization method: Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | Preg + | Preg -
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | Day 5–6 | 22 | 42 | 64
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | Day 2–3 | 25 | 55 | 80
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | 47 | 97 | 144
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | | Lower 95% CI | Upper 95 % CI
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | Rel risk | 1.10 | 0.69 | 1.76
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | 2) Ongoing pregnancy:
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | Preg + | Preg -
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | Day 5–6 | 18 | 46 | 64
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | Day 2–3 | 23 | 57 | 80
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | 41 | 103 | 144
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | | Lower 95% CI | Upper 95 % CI
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | Rel risk | 0.98 | 0.58 | 1.65
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | 3) Twins:
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | Preg + | Preg -
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | Day 5–6 | 2 | 20 | 22
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | Day 2–3 | 4 | 21 | 25
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | 6 | 41 | 47
Hreinsson, Rosenlund, Fridstrom, et al., 2004 #10540 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes (twins) Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 0.57 | 0.11 | 2.81
Hsieh, Tsai, and Chang, 2000 #6580 | Geographical location: Taichung, Taiwan Study dates: July 1998–June 1999 Size of population (no. of patients): 359 Number of cycles analyzed: 359 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to transfer day 2 or day 5 | Age: Mean (SD): Day 2: 32.9 (3.1); Day 5: 32.5 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire group Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments:; - Randomization method not described; - Large discrepancy in arms not explained; - Significantly more embryos/transfer in day 2 group (3.7 vs 2.1); Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Hsieh, Tsai, and Chang, 2000 #6580 | | Age: Mean (SD): Day 2: 32.9 (3.1); Day 5: 32.5 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire group Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Hsieh, Tsai, and Chang, 2000 #6580 | | Age: Mean (SD): Day 2: 32.9 (3.1); Day 5: 32.5 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire group Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Day 5 | 84 | 117 | 201
Hsieh, Tsai, and Chang, 2000 #6580 | | Age: Mean (SD): Day 2: 32.9 (3.1); Day 5: 32.5 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire group Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Day 2 | 59 | 99 | 158
Hsieh, Tsai, and Chang, 2000 #6580 | | Age: Mean (SD): Day 2: 32.9 (3.1); Day 5: 32.5 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire group Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 143 | 216 | 359
Hsieh, Tsai, and Chang, 2000 #6580 | | Age: Mean (SD): Day 2: 32.9 (3.1); Day 5: 32.5 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire group Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Hsieh, Tsai, and Chang, 2000 #6580 | | Age: Mean (SD): Day 2: 32.9 (3.1); Day 5: 32.5 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire group Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.12 | 0.86 | 1.45
Hsieh, Tsai, and Chang, 2000 #6580 | | Age: Mean (SD): Day 2: 32.9 (3.1); Day 5: 32.5 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire group Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy:
Hsieh, Tsai, and Chang, 2000 #6580 | | Age: Mean (SD): Day 2: 32.9 (3.1); Day 5: 32.5 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire group Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Hsieh, Tsai, and Chang, 2000 #6580 | | Age: Mean (SD): Day 2: 32.9 (3.1); Day 5: 32.5 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire group Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Study drug | 65 | 136 | 201
Hsieh, Tsai, and Chang, 2000 #6580 | | Age: Mean (SD): Day 2: 32.9 (3.1); Day 5: 32.5 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire group Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Control | 47 | 111 | 158
Hsieh, Tsai, and Chang, 2000 #6580 | | Age: Mean (SD): Day 2: 32.9 (3.1); Day 5: 32.5 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire group Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 112 | 247 | 359
Hsieh, Tsai, and Chang, 2000 #6580 | | Age: Mean (SD): Day 2: 32.9 (3.1); Day 5: 32.5 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR for entire group Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 1.09 | 0.80 | 1.49
Hughes, Beecroft, Wilkie, et al., 2004 #12420 | Geographical location: Hamilton, London, Toronto, Ottawa, and Vancouver, Canada Study dates: May 2000–April 2002 Size of population (no. of patients): 139 Number of cycles analyzed: 139 Number of cycles per patient: 1.0 Study type: RCT Interventions: Observation for 90 days vs IVF/ICSI within 90 days of randomization | Age: Mean (SD): IVF: 32.9 (3.2); no treatment 33.1(3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 42 (30.2%) Endometriosis: 11 (7.9%) Male factor: 51 (36.7%) Tubal factor: 9 (6.5%) PCOS: 19 (13.7%) Inclusion criteria:; - duration of subfertility >2 years, defined as no live birth during that time;; - no previous IVF treatment; female age 18±39 years; - willingness to commence either IVF within 6 weeks of allocation or a 3 month period of observation without intervention; day 3 serum FSH level of >15 IU/l or the standard level for inclusion in an individual centre's IVF programme, whichever level was lower; semen analysis available within the last 6 months showing an adequate number of sperm to perform ICSI; and evidence of Fallopian tube patency, based on a hysterosalpingogram (HSG) or laparoscopy.; - All had “exhausted” other options; Exclusion criteria:; - women with bilateral Fallopian tube occlusion confirmed by HSG or laparoscopy;; - the use of donor sperm;; - need for sperm recovery procedures; and; - concurrent serious medical illnesses | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Delivery of fetus with heart beat after 24 weeks, or neonate that survives at least 10 minutes Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Hughes, Beecroft, Wilkie, et al., 2004 #12420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Delivery of fetus with heart beat after 24 weeks, or neonate that survives at least 10 minutes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Hughes, Beecroft, Wilkie, et al., 2004 #12420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Delivery of fetus with heart beat after 24 weeks, or neonate that survives at least 10 minutes Multiples: NR Complications: NR | IVF | 21 | 47 | 68 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Hughes, Beecroft, Wilkie, et al., 2004 #12420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Delivery of fetus with heart beat after 24 weeks, or neonate that survives at least 10 minutes Multiples: NR Complications: NR | No Rx | 3 | 68 | 71 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Hughes, Beecroft, Wilkie, et al., 2004 #12420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Delivery of fetus with heart beat after 24 weeks, or neonate that survives at least 10 minutes Multiples: NR Complications: NR | | 24 | 115 | 139 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Hughes, Beecroft, Wilkie, et al., 2004 #12420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Delivery of fetus with heart beat after 24 weeks, or neonate that survives at least 10 minutes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Hughes, Beecroft, Wilkie, et al., 2004 #12420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Delivery of fetus with heart beat after 24 weeks, or neonate that survives at least 10 minutes Multiples: NR Complications: NR | Rel risk | 7.31 | 2.28 | 23.39 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Hughes, Beecroft, Wilkie, et al., 2004 #12420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Delivery of fetus with heart beat after 24 weeks, or neonate that survives at least 10 minutes Multiples: NR Complications: NR | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Hughes, Beecroft, Wilkie, et al., 2004 #12420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Delivery of fetus with heart beat after 24 weeks, or neonate that survives at least 10 minutes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Hughes, Beecroft, Wilkie, et al., 2004 #12420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Delivery of fetus with heart beat after 24 weeks, or neonate that survives at least 10 minutes Multiples: NR Complications: NR | IVF | 20 | 48 | 68 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Hughes, Beecroft, Wilkie, et al., 2004 #12420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Delivery of fetus with heart beat after 24 weeks, or neonate that survives at least 10 minutes Multiples: NR Complications: NR | No Rx | 1 | 70 | 71 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Hughes, Beecroft, Wilkie, et al., 2004 #12420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Delivery of fetus with heart beat after 24 weeks, or neonate that survives at least 10 minutes Multiples: NR Complications: NR | | 21 | 118 | 139 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Hughes, Beecroft, Wilkie, et al., 2004 #12420 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Delivery of fetus with heart beat after 24 weeks, or neonate that survives at least 10 minutes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 20.88 | 2.88 | 151.35
Hugues, Barlow, Rosenwaks, et al., 2003 #17010 | Geographical location: Bondy, France; Oxford, UK; Geneva, Switzerland Study dates: NR Size of population (no. of patients): 131 Number of cycles analyzed: 131 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - Down regulation with GnRH agonist; - Randomized to rFSH prepared either by bioassay (ampules with 75 IU rFSH) or mass equivalent (5.5 micrograms); - 5 day starting dose of 150 IU day | Age: Mean (SD): Mass assay 30.8 (4.0); bioassay 31.4 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - 18–38 years; - Normal menses, endocrine profile, semenanalysis; - BMI <30; - No more than 3 previous attempts; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: Primary outcome = follicle # Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Hugues, Barlow, Rosenwaks, et al., 2003 #17010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: Primary outcome = follicle # Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Hugues, Barlow, Rosenwaks, et al., 2003 #17010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Mass assay | 20 | 46 | 66 | Comments: Primary outcome = follicle # Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Hugues, Barlow, Rosenwaks, et al., 2003 #17010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Bioassay | 17 | 48 | 65 | Comments: Primary outcome = follicle # Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Hugues, Barlow, Rosenwaks, et al., 2003 #17010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 37 | 94 | 131 | Comments: Primary outcome = follicle # Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Hugues, Barlow, Rosenwaks, et al., 2003 #17010 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Primary outcome = follicle # Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.16 | 0.67 | 2.01
Huirne, van Loenen, Donnez, et al., 2006 #52680 | Geographical location: Amsterdam, The Netherlands and Brussels, Belgium Study dates: NR Size of population (no. of patients): 63 Number of cycles analyzed: 63 Number of cycles per patient: 1.0 Study type: RCT Interventions: On cycle day 2 or 3 patients were randomized to receive either OC pretreatment (OC group) or not (control group). The control group started with recombinant human FSH (r-FSH) (Gonal-f™ Serono, Geneva. Switzerland) on day 2 or 3 of a natural cycle. In the OC group, patients started witb daily OC pills (Microgynon 30*; Schering, Madrid. Spain, containing 30 μg ethinyl oestradiol and 150 μg levenorgestrel) on cycle day 2–3 for a variable period of 14–28 days. The date of the last OC intake was to be decided by the investigator on administrative criteria to schedule the initiation of stimulation. Instead of taking a fixed number of days of OC pretreatment, it was decided to vary this duration allowing analyses of its effect on IVF outcome. Gonal-f administration was started 2 or 3 days after OC withdrawal, independent of their bleeding pattern. In both groups, r-FSH was administered daily up to the day of r-HCG administration. The starting dose of r-FSH (150–300 IU) was maintained for 5 days, after which it could be adjusted according to the ovarian response (increase if fewer than 3 oocytes were >11 mm and decrease if a patient was at risk for OHSS) up to a maximal dose of 450 lU/day. From stimulation day 6 up to and including r-HCG day, a GnRH antagonist (antide/Serono) (0.5 mg/ml per day) was given. | Age: Mean (SD): 32.3 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 15 (24%) Endometriosis: 3 (4.7%) Male factor: 35 (55%) Tubal factor: PCOS: Other (specify): 1 (2%) Inclusion criteria: Patients needed to have a regular IVF or lCSl indication (i.e. idiopathic infertility after six unsuccessful intrauterine inseminations, infertility based on male or tubal factor), a spontaneous regular ovulatory menstrual cycle, two ovaries and a normal uterine cavity, age between 18 and 38. Exclusion criteria: FSH >12 IU/1 on cycle day 2–4, BMI > 30 kg/m, abnormal gynecological bleeding, an extrauterine pregnancy within the last 3 months, any previous assisted reproductive technique cycles with fewer than three oocytes or severe OHSS or patients with any contraindication to receive gonadotrophins or oral contraceptives, or presence of polycystic ovarian syndrome (defined as patients with oligomenorrhoea and at least two of the following criteria: elevated LH concentrations, signs of hyperandrogenism, or polycystic ovaries by ultrasound). | Definition(s) of outcome(s): Pregnancy: Biochemical: positive pregnancy test (HCG> 10 IU/l) Clinical: > 1 intrauterine fetal sac on ultrasound at gestational age of 6 weeks. Ongoing: intrauterine heart activity at a gestational age of 12 weeks. Live birth: NR Multiples: NR Complications: Side effects or local skin reactions were recorded daily on a personal diary card | 1) Biochemical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | | Biochem preg + | Biochem preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | OC | 8 | 23 | 31 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | No OC | 13 | 19 | 32 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | Total | 21 | 42 | 63 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | Rel risk | 0.64 | 0.31 | 1.32 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | 2) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | | Clin preg + | Clin preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | OC | 4 | 27 | 31 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | No OC | 12 | 20 | 32 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | Total | 16 | 47 | 63 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | Rel risk | 0.34 | 0.12 | 0.95 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | 3) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | | Ongoing preg + | Ongoing preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | OC | 4 | 27 | 31 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | No OC | 8 | 24 | 32 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | Total | 12 | 51 | 63 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Huirne, van Loenen, Donnez, et al., 2006 #52680 | | | | Rel risk | 0.52 | 0.17 | 1.54 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
4) The treatment was well tolerated. In total, 117 new adverse events were reported in 51 patients. The majority of the adverse events (98%) were reported as mild, five were moderate, and one was severe (tubal infection after oocyte retrieval). The most frequently reported adverse events were injection site reactions (20.5%), headache (22.2%), abdominal pain (12.8%), gastrointestinal discomfort such as nausea (12.0%), fatigue (9.4%), ovarian cyst (5.1%) and mood changes (3.4%). Ovarian hyperstimulation was observed twice, only in the OC group: both cases were considered to be mild, and neither treatment nor admission was required; one of these patients turned out to be pregnant. The number and type of reported adverse events per patient were similar in both groups
Humaidan, Bredkjaer, Bungum, et al., 2005 #42080 | Geographical location: Multicenters in Denmark Study dates: 8/03 – 2/04 Size of population: 122 Number of cycles analyzed: 122 Number of cycles per patient: 1.00 Study type: RCT Interventions: Using GnRH agonist (busereline) vs. 10,000 IU hCG for ovulation induction in GnRH antagonist IVF/ICSI cycles protocol | Age: Range: 25–40 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - FSH and LH < 12IU; - Menstrual cycle between 25d – 34d; - BMI 18–30; - Both ovaries present; - No uterine abnormalities; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Biochemical pregnancy: a plasma βhCG of >10IU/l on 12d after embryo transfer (reported per ET) Chemical pregnancy: an intrauterine gestational sac with a heartbeat 3 wks after a positive hCG test Live birth: NR Multiples: NR Complications: Early pregnancy loss | 1) Clinical pregnancy rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Bredkjaer, Bungum, et al., 2005 #42080 | | | | | Out + | Out - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Bredkjaer, Bungum, et al., 2005 #42080 | | | | Buserelin | 3 | 52 | 55 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Bredkjaer, Bungum, et al., 2005 #42080 | | | | hCG | 24 | 43 | 67 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Bredkjaer, Bungum, et al., 2005 #42080 | | | | Total | 27 | 95 | 122 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Bredkjaer, Bungum, et al., 2005 #42080 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Bredkjaer, Bungum, et al., 2005 #42080 | | | | Rel risk | 0.15 | 0.05 | 0.48 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Bredkjaer, Bungum, et al., 2005 #42080 | | | | 2) No difference in the positive hCG rate (per ET): | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Bredkjaer, Bungum, et al., 2005 #42080 | | | | 29% in Buserelin grp and 44% in hCG grp | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Bredkjaer, Bungum, et al., 2005 #42080 | | | | 3) More early pregnancy loss in Buserelin grp compared to hCG grp: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
79% vs. 4%
Humaidan, Brock, Bungum, et al., 2006 #52690 | Geographical location: Skive, Sweden Study dates: August 2004 to May 2005 Size of population (no. of patients): 152 Number of cycles analyzed: 152 Number of cycles per patient: 1 Study type: RCT Interventions: Mixed frequency electroacupuncture (MFA) Fixed frequency acupuncture (FFA) | Age: Mean (SD): 31.7 (4.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 51 (34%) Endometriosis: 6 (4%) Male factor: 46 (30%) Tubal factor: 29 (19%) Other (specify): 20 (13%) Inclusion criteria: NR Exclusion criteria: Chronic pelvic pain | Definition(s) of outcome(s): Pregnancy: A positive pregnancy test: plasma β-HCG concentration > 10 lU/l. 12 days after embryo transfer. Ongoing clinical pregnancy rate: an intrauterine pregnancy with a heartbeat 8 weeks after a positive β-HCG test (i.e. 10 weeks of pregnancy). Live birth: NR Multiples: NR Complications: Pain assessed using visual analog scale (VAS) | 1) Positive pregnancy test: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Brock, Bungum, et al., 2006 #52690 | | | | | Pos preg test + | Pos preg test - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Brock, Bungum, et al., 2006 #52690 | | | | MFA | 27 | 49 | 76 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Brock, Bungum, et al., 2006 #52690 | | | | FFA | 29 | 47 | 76 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Brock, Bungum, et al., 2006 #52690 | | | | Total | 56 | 96 | 152 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Brock, Bungum, et al., 2006 #52690 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Brock, Bungum, et al., 2006 #52690 | | | | Rel risk | 0.93 | 0.61 | 1.41 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Brock, Bungum, et al., 2006 #52690 | | | | 2) Ongoing clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Brock, Bungum, et al., 2006 #52690 | | | | | Clincal preg + | Clinical preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Brock, Bungum, et al., 2006 #52690 | | | | MFA | 29 | 47 | 76 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Brock, Bungum, et al., 2006 #52690 | | | | FFA | 32 | 44 | 76 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Brock, Bungum, et al., 2006 #52690 | | | | Total | 61 | 91 | 152 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Brock, Bungum, et al., 2006 #52690 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Brock, Bungum, et al., 2006 #52690 | | | | Rel risk | 0.91 | 0.61 | 1.34 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
3) Similar analgesic effect
Humaidan, Bungum, Bungum, et al., 2004 #13150 | Geographical location: Copenhagen, Denmark Study dates: Nov 2001–Oct 2002 Size of population: Grp 1: 116 Grp 2: 115 Number of cycles analyzed: 231 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: Received rLH during IVF stimulation starting on day 8 of stimulation Grp 2: Control All received luteal downregulation with GnRHa and stimulation with rFSH. | Age: Grp 1: Mean (SD): 30.8 (3.9) Range: 23–40 Grp 2: Mean (SD): 30.5 (4) Range: 22–39 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1: Unexplained infertility: 20 [17] Endometriosis: 5 [4] Male factor: 42 [36] Tubal factor: 33 [29] PCOS: 16 [14] Grp 2: Unexplained infertility: 23 [20] Endometriosis: 1 [1] Male factor: 46 [40] Tubal factor: 36 [31] PCOS: 9 [8] Inclusion criteria:; - Age < 40; - Baseline FSH < 10; - Cycles 25d–34d; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments:; - Embryo quality and transfer day NR; - A priori sample size based on absolute difference of 10%; Quality assessment: Randomization method: + Blinding: single Dropout rate < 20%: + Adequacy of randomization concealment: +
Humaidan, Bungum, Bungum, et al., 2004 #13150 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total
Humaidan, Bungum, Bungum, et al., 2004 #13150 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | rFSH + rLH | 42 | 74 | 116
Humaidan, Bungum, Bungum, et al., 2004 #13150 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | rFSH | 35 | 80 | 115
Humaidan, Bungum, Bungum, et al., 2004 #13150 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | Total | 77 | 154 | 231
Humaidan, Bungum, Bungum, et al., 2004 #13150 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Humaidan, Bungum, Bungum, et al., 2004 #13150 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.19 | 0.82 | 1.72
Humaidan, Bungum, Bungum, et al., 2004 #13150 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | 2) Clinical pregnancy, women 35 and older:
Humaidan, Bungum, Bungum, et al., 2004 #13150 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Humaidan, Bungum, Bungum, et al., 2004 #13150 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | Study group | 7 | 14 | 21
Humaidan, Bungum, Bungum, et al., 2004 #13150 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | Control | 4 | 14 | 18
Humaidan, Bungum, Bungum, et al., 2004 #13150 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | | 11 | 28 | 39
Humaidan, Bungum, Bungum, et al., 2004 #13150 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Humaidan, Bungum, Bungum, et al., 2004 #13150 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.50 | 0.52 | 4.31
Rates identical in women <35 years
Humaidan, Bungum, Bungum, et al., 2006 #52700 | Geographical location: Copenhagen, Denmark Study dates: Dec 2004–May 2005 Size of population (no. of patients): 45 Number of cycles analyzed: 45 Number of cycles per patient: 1.0 Study type: RCT Interventions: GnRH antagonist/FSH COH; randomized to ovulation triggering with (a) 10,000 IU hcg, (b) buserelin 0.5 mg + 1500 IU hCG 12 hours later, (c) buserelin 0.5 mg + 1500 IU hCG 35 hours later (immediately after oocyte retrieval) | Age: NR Race/ethnicity (n [%]): White: 45 (100%) Diagnoses (n [%]): NR Inclusion criteria:; (i) female age >25 and <40 years;; (ii) baseline FSH and LH <12 IU/1;; (iii) menstrual cycles between 25 and 34 days;; (iv) body mass index (BMI) >18 and <30;; (v) both ovaries present;; (vi) absence of uterine abnormalities.; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy, 10,000 IU hCG vs GnRH agonist + 1500 IU hCG 12 hours later: | | | | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | GnRHa + hCG 12 hours | 2 | 15 | 17 | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | hCG | 8 | 7 | 15 | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | | 10 | 22 | 32 | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.22 | 0.06 | 0.88 | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | 2) Clinical pregnancy, 10,000 IU hCG vs GnRH agonist + 1500 IU hCG 35 hours later: | | | | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | GnRHa + hCG 35 hours | 6 | 7 | 13 | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | hCG | 8 | 7 | 15 | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | | 14 | 14 | 28 | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.87 | 0.41 | 1.84 | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | 3) Clinical pregnancy, 10,000 IU hCG vs GnRH agonist + 1500 IU hCG 35 hours later: | | | | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | GnRHa + hCG 35 hours | 6 | 7 | 13 | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | GnRHa + hCG 12 hours | 2 | 15 | 17 | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | | 8 | 22 | 30 | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Humaidan, Bungum, Bungum, et al., 2006 #52700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 3 weeks after + serum hCG Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Rel risk | 3.92 | 0.94 | 16.36
Humaidan and Stener-Victorin, 2004 #58270 | Geographical location: Skive, Denmark Study dates: Apr 2002–Dec 2002 Size of population (no. of patients): 200 Number of cycles analyzed: 200 Number of cycles per patient: 1.0 Study type: RCT Interventions: Oocyte retrieval with paracervical block and (a) electroacupuncture or (b) benzodiazepine/alfentanil (conventional) | Age: Mean (SD): Acupuncture: 30.5 Conventional: 31.5 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 56 (28%) Endometriosis: 8 (4%) Male factor: 57 (29%) Tubal factor: 48 (24%) PCOS: 15 (7%) Other or combined: 26 (13%) Inclusion criteria: Scheduled for embryo transfer for IVF Exclusion criteria: None | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain on VAS scale | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: +
Humaidan and Stener-Victorin, 2004 #58270 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain on VAS scale | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: +
Humaidan and Stener-Victorin, 2004 #58270 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain on VAS scale | Electroacupuncture | 46 | 54 | 100 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: +
Humaidan and Stener-Victorin, 2004 #58270 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain on VAS scale | Conventional | 50 | 50 | 100 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: +
Humaidan and Stener-Victorin, 2004 #58270 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain on VAS scale | Total | 96 | 104 | 200 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: +
Humaidan and Stener-Victorin, 2004 #58270 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain on VAS scale | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: +
Humaidan and Stener-Victorin, 2004 #58270 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain on VAS scale | Rel risk | 0.92 | 0.69 | 1.23 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: +
2) No difference in pain on VAS scale
Hwang, Seow, Lin, et al., 2004 #11100 | Geographical location: Taipei, Taiwan Study dates: Jan – Dec 2003 Size of population: Grp 1: 27 Grp 2: 29 Number of cycles analyzed: 56 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: ICSI with Diane OCP pretreatment followed by a Cetrorelix Antagonist + hMG Grp 2: ICSI with long GnRHa downregulation followed by hMG | Age: Grp 1: Mean (SD): 31.4 (3.5) Grp 2: Mean (SD): 31.7 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100 Inclusion criteria:; - PCOS defined by oligo or amenorrhea, anovulation by BBT or serum P4, USD of ovary showing > 10 peripheral follicles, and 1 of 2 hormonal abnormalities, including increased LH:FSH ratio or T > 0.8 ng/mL; Exclusion criteria:; - Age > 38; - Diagnoses of CAH, Cushing's, androgen producing tumor hyperprolactinemia, or thyroid dysfunction | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: OHSS, SAB | 1) Clinical pregnancy: | | | | Comments:; - Low power; - Dropout rate of 7.4% in Grp 1 and 17.2% in Grp 2; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hwang, Seow, Lin, et al., 2004 #11100 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: OHSS, SAB | | Preg + | Preg - | Total | Comments:; - Low power; - Dropout rate of 7.4% in Grp 1 and 17.2% in Grp 2; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hwang, Seow, Lin, et al., 2004 #11100 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: OHSS, SAB | Grp 1 | 10 | 17 | 27 | Comments:; - Low power; - Dropout rate of 7.4% in Grp 1 and 17.2% in Grp 2; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hwang, Seow, Lin, et al., 2004 #11100 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: OHSS, SAB | Grp 2 | 10 | 19 | 29 | Comments:; - Low power; - Dropout rate of 7.4% in Grp 1 and 17.2% in Grp 2; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hwang, Seow, Lin, et al., 2004 #11100 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: OHSS, SAB | Total | 20 | 36 | 56 | Comments:; - Low power; - Dropout rate of 7.4% in Grp 1 and 17.2% in Grp 2; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hwang, Seow, Lin, et al., 2004 #11100 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: OHSS, SAB | | Value | Lower 95% CI | Upper 95% CI | Comments:; - Low power; - Dropout rate of 7.4% in Grp 1 and 17.2% in Grp 2; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hwang, Seow, Lin, et al., 2004 #11100 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: OHSS, SAB | Rel risk | 1.07 | 0.53 | 2.17 | Comments:; - Low power; - Dropout rate of 7.4% in Grp 1 and 17.2% in Grp 2; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hwang, Seow, Lin, et al., 2004 #11100 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: OHSS, SAB | 2) SAB: | | | | Comments:; - Low power; - Dropout rate of 7.4% in Grp 1 and 17.2% in Grp 2; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hwang, Seow, Lin, et al., 2004 #11100 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: OHSS, SAB | Grp 1: 10% | | | | Comments:; - Low power; - Dropout rate of 7.4% in Grp 1 and 17.2% in Grp 2; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hwang, Seow, Lin, et al., 2004 #11100 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: OHSS, SAB | Grp 2: 20% | | | | Comments:; - Low power; - Dropout rate of 7.4% in Grp 1 and 17.2% in Grp 2; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hwang, Seow, Lin, et al., 2004 #11100 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: OHSS, SAB | p = NS | | | | Comments:; - Low power; - Dropout rate of 7.4% in Grp 1 and 17.2% in Grp 2; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hwang, Seow, Lin, et al., 2004 #11100 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: OHSS, SAB | 3) OHSS: | | | | Comments:; - Low power; - Dropout rate of 7.4% in Grp 1 and 17.2% in Grp 2; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hwang, Seow, Lin, et al., 2004 #11100 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: OHSS, SAB | Grp 1: 8% | | | | Comments:; - Low power; - Dropout rate of 7.4% in Grp 1 and 17.2% in Grp 2; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Hwang, Seow, Lin, et al., 2004 #11100 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: OHSS, SAB | Grp 2: 8.3% | | | | Comments:; - Low power; - Dropout rate of 7.4% in Grp 1 and 17.2% in Grp 2; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
p = NS
Ingerslev, Hojgaard, Hindkjaer, et al., 2001 #5510 | Geographical location: Aarhus, Denmark Study dates: Aug 1997–Dec 1997 Size of population (no. of patients): 132 Number of cycles analyzed: 225 Number of cycles per patient: 1.7 Study type: RCT Interventions: Randomized to (a) clomiphene citrate 100 mg/day cycles day 3–7, or (b) no treatment; - No other stimulation; - hCG given based on ultrasound monitoring | Age: Mean (SD): Clomiphene 30.2 (2.9), control 30.7 (2.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 52 (21.5%) Male factor: 74 (30.6%) Tubal factor: 115 (47.5%) Inclusion criteria:; - <35 years; - Unexplained, tubal, or severe male factor; - Regular menses; - No previous IVF; - 2 ovaries; Exclusion criteria: NR | Definition(s) of outcome(s): Clinical Pregnancy: Intrauterine pregnancy with FHR 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy | | | | Comments:; - High prevalence of smoking; - Allocated treatment continued for subsequent cycles, after washout; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ingerslev, Hojgaard, Hindkjaer, et al., 2001 #5510 | | | Definition(s) of outcome(s): Clinical Pregnancy: Intrauterine pregnancy with FHR 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Ingerslev, Hojgaard, Hindkjaer, et al., 2001 #5510 | | | Definition(s) of outcome(s): Clinical Pregnancy: Intrauterine pregnancy with FHR 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Clomiphene | 20 | 48 | 68
Ingerslev, Hojgaard, Hindkjaer, et al., 2001 #5510 | | | Definition(s) of outcome(s): Clinical Pregnancy: Intrauterine pregnancy with FHR 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Control | 4 | 60 | 64
Ingerslev, Hojgaard, Hindkjaer, et al., 2001 #5510 | | | Definition(s) of outcome(s): Clinical Pregnancy: Intrauterine pregnancy with FHR 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | 24 | 108 | 132
Ingerslev, Hojgaard, Hindkjaer, et al., 2001 #5510 | | | Definition(s) of outcome(s): Clinical Pregnancy: Intrauterine pregnancy with FHR 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 4.71 | 1.70 | 13.02
Isik, Vicdan, Kaba, et al., 2000 #7460 | Geographical location: Ankara, Turkey Study dates: 4-1-98 to 10-31-98 Size of population: Grp 1: 22 Grp 2: 24 Number of cycles analyzed: 46 Number of cycles per patient: 1.0 Study type: RCT Interventions: Grp 1: Zona intact blastocyst transfer Grp 2: Zona free blastocyst transfer | Age: Grp 1: Mean (SD): 29.1 (3.6) Median: NR Range: NR Grp 2: Mean (SD): 30.5 (5.2) Median: NR Range: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: More than 5 day 3 cleaved embryos Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | 1) Pregnancy rate: | | | | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | | Preg + | Preg - | | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | Zona free | 15 | 9 | 24 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | Zona intact | 10 | 12 | 22 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | | 25 | 21 | 46 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | Rel risk | 1.38 | 0.79 | 2.39 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | 2) Ongoing pregnancy: | | | | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | | Preg + | Preg - | | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | Study drug | 11 | 13 | 24 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | Control | 6 | 16 | 22 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | | 17 | 29 | 46 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | | | Lower 95% CI | Upper 95% CI | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | Rel risk | 1.68 | 0.75 | 3.77 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | 3) Twins: | | | | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | | Single-ton | Twin | Total | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | Zona intact | 8 | 2 | 10 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | Zona free | 13 | 2 | 15 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | Total | 21 | 4 | 25 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isik, Vicdan, Kaba, et al., 2000 #7460 | | | Definition(s) of outcome(s): Pregnancy: Clinical - presence of fetal pole with or w/o heart beat Ongoing - > 12 wks EGA Live birth: NR Multiples: Yes (twins) Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.92 | 0.64 | 1.33
Isikoglu, Ozgur, and Oehninger, 2007 #71450 | Geographical location: Antalya, Turkey Study dates: NR Size of population (no. of patients): 181 Number of cycles analyzed: 181 Number of cycles per patient: 1.0 Study type: RCT Interventions: Long protocol GnRH agonist suppression, randomized to (a) continued agonist through day 12 after embryo transfer, vs. (b) day of hCG administration. ICSI for fertilization | Age: Mean (SD): Luteal GnRH: 30. 1 (4.9) Control: 30.1 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Fetal cardiac activity 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isikoglu, Ozgur, and Oehninger, 2007 #71450 | | Age: Mean (SD): Luteal GnRH: 30. 1 (4.9) Control: 30.1 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Fetal cardiac activity 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isikoglu, Ozgur, and Oehninger, 2007 #71450 | | Age: Mean (SD): Luteal GnRH: 30. 1 (4.9) Control: 30.1 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Fetal cardiac activity 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Luteal GnRH | 44 | 46 | 90 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isikoglu, Ozgur, and Oehninger, 2007 #71450 | | Age: Mean (SD): Luteal GnRH: 30. 1 (4.9) Control: 30.1 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Fetal cardiac activity 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Control | 45 | 46 | 91 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isikoglu, Ozgur, and Oehninger, 2007 #71450 | | Age: Mean (SD): Luteal GnRH: 30. 1 (4.9) Control: 30.1 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Fetal cardiac activity 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Total | 89 | 92 | 181 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isikoglu, Ozgur, and Oehninger, 2007 #71450 | | Age: Mean (SD): Luteal GnRH: 30. 1 (4.9) Control: 30.1 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Fetal cardiac activity 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isikoglu, Ozgur, and Oehninger, 2007 #71450 | | Age: Mean (SD): Luteal GnRH: 30. 1 (4.9) Control: 30.1 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Fetal cardiac activity 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.99 | 0.74 | 1.33 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isikoglu, Ozgur, and Oehninger, 2007 #71450 | | Age: Mean (SD): Luteal GnRH: 30. 1 (4.9) Control: 30.1 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Fetal cardiac activity 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isikoglu, Ozgur, and Oehninger, 2007 #71450 | | Age: Mean (SD): Luteal GnRH: 30. 1 (4.9) Control: 30.1 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Fetal cardiac activity 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | Out + | Out - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isikoglu, Ozgur, and Oehninger, 2007 #71450 | | Age: Mean (SD): Luteal GnRH: 30. 1 (4.9) Control: 30.1 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Fetal cardiac activity 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Exp + | 34 | 56 | 90 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isikoglu, Ozgur, and Oehninger, 2007 #71450 | | Age: Mean (SD): Luteal GnRH: 30. 1 (4.9) Control: 30.1 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Fetal cardiac activity 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Exp - | 32 | 59 | 91 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isikoglu, Ozgur, and Oehninger, 2007 #71450 | | Age: Mean (SD): Luteal GnRH: 30. 1 (4.9) Control: 30.1 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Fetal cardiac activity 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Total | 66 | 115 | 181 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Isikoglu, Ozgur, and Oehninger, 2007 #71450 | | Age: Mean (SD): Luteal GnRH: 30. 1 (4.9) Control: 30.1 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Fetal cardiac activity 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 1.07 | 0.73 | 1.58
Jaroudi, Al-Hassan, Sieck, et al., 2004 #13750 | Geographical location: Riyadh, Saudi Arabia Study dates: Dec 2001–Oct 2002 Size of population (no. of patients): 302 (7 dropouts, 41 no transfers) Number of cycles analyzed: 156 in paper, 302 included here in intent-to-treat Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to transfer of 2 embryos on (a) day 1 or (b) day 3 | Age: Mean (SD): Day 1: 31.1, Day 3: 31.5 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 26 (8.6) Endometriosis: Male factor: 171 (56.6%) Tubal factor: 36 (11.9%) Other (unspecified): 21 (7.0%) Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + hCG, ultrasound 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy (intent-to-treat): | | | | Comments: Sample size powered to detect 15% absolute difference Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Jaroudi, Al-Hassan, Sieck, et al., 2004 #13750 | | | Definition(s) of outcome(s): Pregnancy: + hCG, ultrasound 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: Sample size powered to detect 15% absolute difference Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Jaroudi, Al-Hassan, Sieck, et al., 2004 #13750 | | | Definition(s) of outcome(s): Pregnancy: + hCG, ultrasound 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Day 1 | 34 | 117 | 151 | Comments: Sample size powered to detect 15% absolute difference Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Jaroudi, Al-Hassan, Sieck, et al., 2004 #13750 | | | Definition(s) of outcome(s): Pregnancy: + hCG, ultrasound 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Day 3 | 55 | 96 | 151 | Comments: Sample size powered to detect 15% absolute difference Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Jaroudi, Al-Hassan, Sieck, et al., 2004 #13750 | | | Definition(s) of outcome(s): Pregnancy: + hCG, ultrasound 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | 89 | 213 | 302 | Comments: Sample size powered to detect 15% absolute difference Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Jaroudi, Al-Hassan, Sieck, et al., 2004 #13750 | | | Definition(s) of outcome(s): Pregnancy: + hCG, ultrasound 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Sample size powered to detect 15% absolute difference Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Jaroudi, Al-Hassan, Sieck, et al., 2004 #13750 | | | Definition(s) of outcome(s): Pregnancy: + hCG, ultrasound 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.62 | 0.43 | 0.89 | Comments: Sample size powered to detect 15% absolute difference Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Jaroudi, Al-Hassan, Sieck, et al., 2004 #13750 | | | Definition(s) of outcome(s): Pregnancy: + hCG, ultrasound 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy (intent-to-treat): | | | | Comments: Sample size powered to detect 15% absolute difference Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Jaroudi, Al-Hassan, Sieck, et al., 2004 #13750 | | | Definition(s) of outcome(s): Pregnancy: + hCG, ultrasound 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: Sample size powered to detect 15% absolute difference Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Jaroudi, Al-Hassan, Sieck, et al., 2004 #13750 | | | Definition(s) of outcome(s): Pregnancy: + hCG, ultrasound 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Day 1 | 27 | 124 | 151 | Comments: Sample size powered to detect 15% absolute difference Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Jaroudi, Al-Hassan, Sieck, et al., 2004 #13750 | | | Definition(s) of outcome(s): Pregnancy: + hCG, ultrasound 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Day 3 | 42 | 109 | 151 | Comments: Sample size powered to detect 15% absolute difference Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Jaroudi, Al-Hassan, Sieck, et al., 2004 #13750 | | | Definition(s) of outcome(s): Pregnancy: + hCG, ultrasound 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | 69 | 233 | 302 | Comments: Sample size powered to detect 15% absolute difference Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Jaroudi, Al-Hassan, Sieck, et al., 2004 #13750 | | | Definition(s) of outcome(s): Pregnancy: + hCG, ultrasound 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Sample size powered to detect 15% absolute difference Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Jaroudi, Al-Hassan, Sieck, et al., 2004 #13750 | | | Definition(s) of outcome(s): Pregnancy: + hCG, ultrasound 5 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.64 | 0.42 | 0.99 | Comments: Sample size powered to detect 15% absolute difference Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
3) Results similar when only cycles where ET occurred analyzed
Jelinkova, Pavelkova, Strehler, et al., 2003 #70000 | Geographical location: Ulm, Germany Study dates: NR Size of population (no. of patients): 257 Number of cycles analyzed: 257 Number of cycles per patient: 1.0 Study type: RCT Interventions: Day 5 transfers randomized to (a) chemical zona removal vs (b) no thinning | Age: Mean (SD): Zona thinning: 32.3 (4.2) No thinning: 32.1 (3.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - At least 2 previous implantation failures; - 2–3 embryos reaching morula or blastocyst stage after 5 days of in vitro culture; - Homogenous morphology of transferred embryos as optimal, poor, or delayed, according to investigators' classification system; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 10 weeks after retrieval Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Jelinkova, Pavelkova, Strehler, et al., 2003 #70000 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 10 weeks after retrieval Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Jelinkova, Pavelkova, Strehler, et al., 2003 #70000 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 10 weeks after retrieval Live birth: NR Multiples: NR Complications: NR | Zona thinning | 59 | 69 | 128 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Jelinkova, Pavelkova, Strehler, et al., 2003 #70000 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 10 weeks after retrieval Live birth: NR Multiples: NR Complications: NR | Control | 40 | 89 | 129 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Jelinkova, Pavelkova, Strehler, et al., 2003 #70000 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 10 weeks after retrieval Live birth: NR Multiples: NR Complications: NR | Total | 99 | 158 | 257 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Jelinkova, Pavelkova, Strehler, et al., 2003 #70000 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 10 weeks after retrieval Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Rel risk | 1.49 | 1.08 | 2.04
Karaki, Samarraie, Younis, et al., 2002 #2960 | Geographical location: Amman, Jordan Study dates: June 1999–June 2000 Size of population: Grp 1: 82 Grp 2: 80 Number of cycles analyzed: 162 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: Day 3 ET after IVF/ICSI Grp 2: Blastocyst transfer after IVF/ICSI | Age: Mean (SD): Grp 1: 29.2 (5) Grp 2: 30 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1: Unexplained infertility:4 [5] Endometriosis: 6 [7] Male factor: 42 [51] Tubal factor: 8 [10] PCOS: 7 [9] Combined male and female: 15 [18] Grp 2: Unexplained infertility:6 [7] Endometriosis: 4 [5] Male factor: 42 [52] Tubal factor: 6 [8] PCOS: 9 [11] Combined male and female: 13 [17] Inclusion criteria: At least 5 2PN embryos on day after TVOR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | 1) Clinical pregnancy rate: | | | | Comments: Bias to higher pregnancy rate in Grp 1due to statistically significantly greater number of embryos transferred, 3.5 vs. 2.0. Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: 11% of Grp 2 did not get transfer but were included in analysis Adequacy of randomization concealment: - (NR)
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg -
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | Blastocyst | 23 | 57 | 80
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | Day 3 | 21 | 61 | 82
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | | 44 | 118 | 162
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | Rel risk | 1.12 | 0.68 | 1.86
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | 2) Multiples:
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | | Mult + | Mult -
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | Blastocyst | 9 | 14 | 23
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | Day 3 | 10 | 11 | 21
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | | 19 | 25 | 44
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | Rel risk | 0.82 | 0.42 | 1.62
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | 3) Multiples greater than 2:
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | Grp 1: 19%
Karaki, Samarraie, Younis, et al., 2002 #2960 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | Grp 2: 4%
p < 0.05
Kattera and Chen, 2003 #15170 | Geographical location: Singapore Study dates: NR Size of population (no. of patients): 259 Number of cycles analyzed: 259 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to co-incubation of ooycte and sperm for; (a) 2 hours vs.; (b) 20 hours | Age: Mean (SD): Short: 35.4 (4.1); Long: 35.1 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 30 (11.6%) Endometriosis: 89 (34.3%) Tubal factor: 31 (12.9%) PCOS: 109 (42.1%) Inclusion criteria: NR Exclusion criteria:; - Very poor responders (those who produced fewer than three follicles); - men with severe oligoasthenoteratozoospermia (density ≤ 5 m/mL, motility ≤ 30% and morphology ≤ 5% as per strict criteria) | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kattera and Chen, 2003 #15170 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kattera and Chen, 2003 #15170 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 2 hours | 63 | 67 | 130 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kattera and Chen, 2003 #15170 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 20 hours | 37 | 92 | 129 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kattera and Chen, 2003 #15170 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 100 | 159 | 259 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kattera and Chen, 2003 #15170 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 1.69 | 1.22 | 2.34
Keay, Lenton, Cooke, et al., 2001 #4330 | Geographical location: Sheffield and Bristol, UK Study dates: NR Size of population (no. of patients): 290 Number of cycles analyzed: 290 Number of cycles per patient: 1.00 Study type: RCT Interventions:; - Norethisterone prior to beginning pituitary suppression with buserelin; - stimulation with rFSH; - nightly dose of either 1 mg dexamethasone or placebo from beginning of gonadotropins until night before oocyte retrieval | Age: Mean (SD): Dexamethasone: 32.5 (3.8) Placebo: 32.2 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 57 (20%) Endometriosis: 21 (7%) Male factor: 88 (30%) Tubal factor: 125 (43%) PCOS: 11 (4%) Inclusion criteria:; - Scheduled for IVF/ICSI; Exclusion criteria:; - ≥ 40 years; - Concurrent use of steroids; - History of IDDM or peptic ulcer | Definition(s) of outcome(s): Pregnancy: Ultrasound confirmation of gestational sac with FHR Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments:; - A priori sample size based on reduction in cancellation rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment:+
Keay, Lenton, Cooke, et al., 2001 #4330 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound confirmation of gestational sac with FHR Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments:; - A priori sample size based on reduction in cancellation rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment:+
Keay, Lenton, Cooke, et al., 2001 #4330 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound confirmation of gestational sac with FHR Live birth: NR Multiples: NR Complications: NR | Dex | 39 | 106 | 145 | Comments:; - A priori sample size based on reduction in cancellation rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment:+
Keay, Lenton, Cooke, et al., 2001 #4330 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound confirmation of gestational sac with FHR Live birth: NR Multiples: NR Complications: NR | Placebo | 25 | 120 | 145 | Comments:; - A priori sample size based on reduction in cancellation rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment:+
Keay, Lenton, Cooke, et al., 2001 #4330 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound confirmation of gestational sac with FHR Live birth: NR Multiples: NR Complications: NR | | 64 | 226 | 290 | Comments:; - A priori sample size based on reduction in cancellation rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment:+
Keay, Lenton, Cooke, et al., 2001 #4330 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound confirmation of gestational sac with FHR Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments:; - A priori sample size based on reduction in cancellation rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment:+
Keay, Lenton, Cooke, et al., 2001 #4330 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound confirmation of gestational sac with FHR Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.56 | 1.00 | 2.44 | Comments:; - A priori sample size based on reduction in cancellation rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment:+
Keay, Lenton, Cooke, et al., 2001 #4330 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound confirmation of gestational sac with FHR Live birth: NR Multiples: NR Complications: NR | 2) Overall cancellation rate: | | | | Comments:; - A priori sample size based on reduction in cancellation rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment:+
Keay, Lenton, Cooke, et al., 2001 #4330 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound confirmation of gestational sac with FHR Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments:; - A priori sample size based on reduction in cancellation rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment:+
Keay, Lenton, Cooke, et al., 2001 #4330 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound confirmation of gestational sac with FHR Live birth: NR Multiples: NR Complications: NR | Study drug | 10 | 135 | 145 | Comments:; - A priori sample size based on reduction in cancellation rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment:+
Keay, Lenton, Cooke, et al., 2001 #4330 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound confirmation of gestational sac with FHR Live birth: NR Multiples: NR Complications: NR | Control | 21 | 124 | 145 | Comments:; - A priori sample size based on reduction in cancellation rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment:+
Keay, Lenton, Cooke, et al., 2001 #4330 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound confirmation of gestational sac with FHR Live birth: NR Multiples: NR Complications: NR | | 31 | 259 | 290 | Comments:; - A priori sample size based on reduction in cancellation rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment:+
Keay, Lenton, Cooke, et al., 2001 #4330 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound confirmation of gestational sac with FHR Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments:; - A priori sample size based on reduction in cancellation rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment:+
Keay, Lenton, Cooke, et al., 2001 #4330 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound confirmation of gestational sac with FHR Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.48 | 0.23 | 0.98 | Comments:; - A priori sample size based on reduction in cancellation rate; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment:+
Greatest benefit for cancellation for poor response (2.8% vs 12.4%); small numbers of cancellations for over-response, but more common in dexamethasone group (4% vs 2%)
Kilani, Dakkak, Ghunaim, et al., 2003 #16640 | Geographical location: Bologna, Italy Study dates: NR Size of population (no. of patients): 100 Number of cycles analyzed: 100 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - GnRH agonist suppression; - Randomized to stimulation with either 150 IU rFSH or 150 IU HP-hMG daily; - Dose maintained until 3 follicles ≥ 18 mm and E2 >600 pg/ml, or 14 days.; - Dose adjusted after 14 days | Age Mean (SD): rFSH 25.9 (5); HP-hMG 27.0 (0.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Normal menstrual cycles; - BMI 18–27; - 3 or fewer previous I VF/ICSI cycles; - PCOS/endometrosis; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: OHSS | 1) Pregnancy: | | | | Comments: Powered on duration and amount of gonadotropin Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Kilani, Dakkak, Ghunaim, et al., 2003 #16640 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: OHSS | | Preg + | Preg - | | Comments: Powered on duration and amount of gonadotropin Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Kilani, Dakkak, Ghunaim, et al., 2003 #16640 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: OHSS | rFSH | 14 | 36 | 50 | Comments: Powered on duration and amount of gonadotropin Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Kilani, Dakkak, Ghunaim, et al., 2003 #16640 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: OHSS | HP-hMG | 15 | 35 | 50 | Comments: Powered on duration and amount of gonadotropin Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Kilani, Dakkak, Ghunaim, et al., 2003 #16640 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: OHSS | | 29 | 71 | 100 | Comments: Powered on duration and amount of gonadotropin Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Kilani, Dakkak, Ghunaim, et al., 2003 #16640 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: OHSS | | | Lower 95% CI | Upper 95 % CI | Comments: Powered on duration and amount of gonadotropin Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Kilani, Dakkak, Ghunaim, et al., 2003 #16640 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: OHSS | Rel risk | 0.93 | 0.51 | 1.72 | Comments: Powered on duration and amount of gonadotropin Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Kilani, Dakkak, Ghunaim, et al., 2003 #16640 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: OHSS | 2) Live birth: | | | | Comments: Powered on duration and amount of gonadotropin Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Kilani, Dakkak, Ghunaim, et al., 2003 #16640 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: OHSS | | Preg + | Preg - | | Comments: Powered on duration and amount of gonadotropin Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Kilani, Dakkak, Ghunaim, et al., 2003 #16640 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: OHSS | rFSH | 11 | 39 | 50 | Comments: Powered on duration and amount of gonadotropin Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Kilani, Dakkak, Ghunaim, et al., 2003 #16640 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: OHSS | HP-hMG | 12 | 38 | 50 | Comments: Powered on duration and amount of gonadotropin Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Kilani, Dakkak, Ghunaim, et al., 2003 #16640 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: OHSS | | 23 | 77 | 100 | Comments: Powered on duration and amount of gonadotropin Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Kilani, Dakkak, Ghunaim, et al., 2003 #16640 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: OHSS | | | Lower 95% CI | Upper 95 % CI | Comments: Powered on duration and amount of gonadotropin Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Kilani, Dakkak, Ghunaim, et al., 2003 #16640 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: OHSS | Rel risk | 0.92 | 0.45 | 1.88 | Comments: Powered on duration and amount of gonadotropin Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
3) Moderate OHSS—1 in rFSH, 3 in HP-hMG
Kjotrod, von During, and Carlsen, 2004 #12090 | Geographical location: Trondheim, Norway Study dates: Jan 2001–June 2002 Size of population: Grp 1: 37 with final analysis of 31 Grp 2: 36 with final analysis of 32 Number of cycles analyzed: 73 Number of cycles per patient: 1.00 Study type: RCT Interventions: IVF/ICSI cycles with long luteal downregulation with GnRHa and stimulation with rFSH Grp 1: Metformin 1000 mg BID for at least 16 wks stopping on day of hCG Grp 2: Control - no metformin | Age: Grp 1: Mean (SD): 28.9 CI 27.6–30.2 Grp 2: Mean (SD): 30.2 CI 29 – 31.5 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1: Endometriosis: 3 [7] Male factor: 22 [31] Tubal factor: 12 [29] PCOS: 100 Above diagnoses in addition to PCOS, not all pts evaluated for each diagnosis Inclusion criteria:; - PCOS by use of > 10 follicles/ovary, oligo/amenorrhea; - At least 1 of 5 abnormal labs including T > 2.0, SHBG < 30, LH/FSH ratio > 2, fastin C-peptide >1.0 and hirsutism; Exclusion criteria:; - DM, renal or liver disease; - Oral steroids; - Abnormal prolactin, TSH, CAH; - Androgen tumor | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | 1) Clinical pregnancy rate overall—intent-to-treat: | | | | Comments:; - Dropouts: Grp 1 16.2%; Grp 2 11.1%; - 6 spontaneous pregnancies in normal weight women; Quality assessment: Randomization method: + Blinding: + - Dropout rate < 20%: + Adequacy of randomization concealment: +
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | | Preg + | Preg -
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | Meformin | 19 | 18 | 37
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | Placebo | 16 | 20 | 36
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | | 35 | 38 | 73
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | | | Lower 95% CI | Upper 95 % CI
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | Rel risk | 1.16 | 0.71 | 1.87
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | 2) Live birth rate (intent-to-treat):
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | | Preg + | Preg -
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | Meformin | 12 | 25 | 37
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | Placebo | 11 | 25 | 36
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | | 23 | 50 | 73
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | | | Lower 95% CI | Upper 95 % CI
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | Rel risk | 1.06 | 0.54 | 2.09
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | 3) OHSS:
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | Grp 1: 3.2%
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | Grp 2: 12.5%
Kjotrod, von During, and Carlsen, 2004 #12090 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac only Live birth: Yes Multiples: NR Complications: OHSS | P = 0.3
4) Outcomes stratified by BMI of < or > 28 showed no difference in clinical pregnancy or live birth but did show statistically significantly higher positive pregnancy test rate in metformin 1 of the < 28 BMI compared to placebo
Kleinstein and Luteal Phase Study Group, 2005 #40060 | Geographical location: Magdeburg, Germany Study dates: 7/99 – 9/2001 Size of population: Grp 1: Utrogest-218 Grp 2: Crinone-212 Number of cycles analyzed: 430 Number of cycles per patient: 1.0 Study type: RCT Interventions: Women undergoing 1^st^ attempt at IVF/ICSI randomized to receive vaginal progesterone in oil 200 mg TID (Utrogest) or Crinone 8% progesterone gel vaginally BID | Age: Grp 1: Mean (SD): 30.7 [2.9] Grp 2: Mean (SD): 30.1 [3.0] Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1 Unexplained infertility: NR Endometriosis: 12 [5.5] Male factor: 104 [47.7] Tubal factor: 66 [30.3] PCOS: 0 Other: 36 [16.5] Grp 2 Unexplained infertility: NR Endometriosis: 16 [7.6] Male factor: 117 [55.2] Tubal factor: 48 [22.6] PCOS: 0 Other: 31 [14.6] Inclusion criteria:; - First attempt; - Age ≥18 and ≤35.; - Normal PAP; Exclusion criteria: Contraindication to P treatment | Definition(s) of outcome(s): Pregnancy: ongoing at end of 12^th^ wk Live birth: NR Multiples: NR Complications: SAB | 1) Pregnancy rate grp 1 vs 2: | | | | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: +
Kleinstein and Luteal Phase Study Group, 2005 #40060 | | | Definition(s) of outcome(s): Pregnancy: ongoing at end of 12^th^ wk Live birth: NR Multiples: NR Complications: SAB | | pg pos | pg neg | Total | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: +
Kleinstein and Luteal Phase Study Group, 2005 #40060 | | | Definition(s) of outcome(s): Pregnancy: ongoing at end of 12^th^ wk Live birth: NR Multiples: NR Complications: SAB | Utrogest | 55 | 163 | 218 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: +
Kleinstein and Luteal Phase Study Group, 2005 #40060 | | | Definition(s) of outcome(s): Pregnancy: ongoing at end of 12^th^ wk Live birth: NR Multiples: NR Complications: SAB | Crinone | 47 | 165 | 212 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: +
Kleinstein and Luteal Phase Study Group, 2005 #40060 | | | Definition(s) of outcome(s): Pregnancy: ongoing at end of 12^th^ wk Live birth: NR Multiples: NR Complications: SAB | Total | 102 | 328 | 430 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: +
Kleinstein and Luteal Phase Study Group, 2005 #40060 | | | Definition(s) of outcome(s): Pregnancy: ongoing at end of 12^th^ wk Live birth: NR Multiples: NR Complications: SAB | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: +
Kleinstein and Luteal Phase Study Group, 2005 #40060 | | | Definition(s) of outcome(s): Pregnancy: ongoing at end of 12^th^ wk Live birth: NR Multiples: NR Complications: SAB | Rel risk | 1.14 | 0.81 | 1.60 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: +
Kleinstein and Luteal Phase Study Group, 2005 #40060 | | | Definition(s) of outcome(s): Pregnancy: ongoing at end of 12^th^ wk Live birth: NR Multiples: NR Complications: SAB | 2) SAB rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: +
Kleinstein and Luteal Phase Study Group, 2005 #40060 | | | Definition(s) of outcome(s): Pregnancy: ongoing at end of 12^th^ wk Live birth: NR Multiples: NR Complications: SAB | | SAB | No SAB | Total | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: +
Kleinstein and Luteal Phase Study Group, 2005 #40060 | | | Definition(s) of outcome(s): Pregnancy: ongoing at end of 12^th^ wk Live birth: NR Multiples: NR Complications: SAB | Utrogest | 10 | 45 | 55 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: +
Kleinstein and Luteal Phase Study Group, 2005 #40060 | | | Definition(s) of outcome(s): Pregnancy: ongoing at end of 12^th^ wk Live birth: NR Multiples: NR Complications: SAB | Crinone | 9 | 38 | 47 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: +
Kleinstein and Luteal Phase Study Group, 2005 #40060 | | | Definition(s) of outcome(s): Pregnancy: ongoing at end of 12^th^ wk Live birth: NR Multiples: NR Complications: SAB | Total | 19 | 83 | 102 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: +
Kleinstein and Luteal Phase Study Group, 2005 #40060 | | | Definition(s) of outcome(s): Pregnancy: ongoing at end of 12^th^ wk Live birth: NR Multiples: NR Complications: SAB | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.95 | 0.42 | 2.14
Klinkert, Broekmans, Looman, et al., 2005 #9240 | Geographical location: Rotterdam, Netherlands Study dates: May 2001 – Nov 2002 Size of population: Grp 1: 26 Grp 2: 26 Number of cycles analyzed: 52 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: std dose of 150 IU rFSH Grp 2: double dose of 300 IU rFSH First IVF/ICSI cycle in pts with low antral follicle count (AFC) | Age: Grp 1: Mean (SD): 40.4 Range: 36.6–44.5 Grp 2: Mean (SD): 42.2 Range: 33.7–44.6 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1: Unexplained infertility: 9 [34.6] Male factor: 12 [46.2] Tubal factor: 5 [19.2] Grp 2: Unexplained infertility: 7 [26.9] Male factor: 10 [38.5] Tubal factor: 9 [34.6]] Inclusion criteria:; - Less than 5 antral follicles 2–5 mm; - Regular cycles of 25–35 days; - Presence of both ovaries; Exclusion criteria: Ovarian cyst > 3 cm | Definition(s) of outcome(s): Pregnancy: Clinical, not defined Ongoing pregnancy: +FCM at 12 wks EGA Live birth: NR Multiples: Reported, but none occurred Complications: NR | 1) Clinical pregnancy: | | | | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Klinkert, Broekmans, Looman, et al., 2005 #9240 | | | Definition(s) of outcome(s): Pregnancy: Clinical, not defined Ongoing pregnancy: +FCM at 12 wks EGA Live birth: NR Multiples: Reported, but none occurred Complications: NR | | Preg + | Preg - | | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Klinkert, Broekmans, Looman, et al., 2005 #9240 | | | Definition(s) of outcome(s): Pregnancy: Clinical, not defined Ongoing pregnancy: +FCM at 12 wks EGA Live birth: NR Multiples: Reported, but none occurred Complications: NR | 300 IU | 1 | 25 | 26 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Klinkert, Broekmans, Looman, et al., 2005 #9240 | | | Definition(s) of outcome(s): Pregnancy: Clinical, not defined Ongoing pregnancy: +FCM at 12 wks EGA Live birth: NR Multiples: Reported, but none occurred Complications: NR | 150 IU | 3 | 23 | 26 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Klinkert, Broekmans, Looman, et al., 2005 #9240 | | | Definition(s) of outcome(s): Pregnancy: Clinical, not defined Ongoing pregnancy: +FCM at 12 wks EGA Live birth: NR Multiples: Reported, but none occurred Complications: NR | | 4 | 48 | 52 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Klinkert, Broekmans, Looman, et al., 2005 #9240 | | | Definition(s) of outcome(s): Pregnancy: Clinical, not defined Ongoing pregnancy: +FCM at 12 wks EGA Live birth: NR Multiples: Reported, but none occurred Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Klinkert, Broekmans, Looman, et al., 2005 #9240 | | | Definition(s) of outcome(s): Pregnancy: Clinical, not defined Ongoing pregnancy: +FCM at 12 wks EGA Live birth: NR Multiples: Reported, but none occurred Complications: NR | Rel risk | 0.33 | 0.04 | 3.00 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Klinkert, Broekmans, Looman, et al., 2005 #9240 | | | Definition(s) of outcome(s): Pregnancy: Clinical, not defined Ongoing pregnancy: +FCM at 12 wks EGA Live birth: NR Multiples: Reported, but none occurred Complications: NR | 2) Ongoing pregnancy: | | | | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Klinkert, Broekmans, Looman, et al., 2005 #9240 | | | Definition(s) of outcome(s): Pregnancy: Clinical, not defined Ongoing pregnancy: +FCM at 12 wks EGA Live birth: NR Multiples: Reported, but none occurred Complications: NR | | Preg + | Preg - | | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Klinkert, Broekmans, Looman, et al., 2005 #9240 | | | Definition(s) of outcome(s): Pregnancy: Clinical, not defined Ongoing pregnancy: +FCM at 12 wks EGA Live birth: NR Multiples: Reported, but none occurred Complications: NR | Study drug | 1 | 25 | 26 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Klinkert, Broekmans, Looman, et al., 2005 #9240 | | | Definition(s) of outcome(s): Pregnancy: Clinical, not defined Ongoing pregnancy: +FCM at 12 wks EGA Live birth: NR Multiples: Reported, but none occurred Complications: NR | Control | 2 | 24 | 26 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Klinkert, Broekmans, Looman, et al., 2005 #9240 | | | Definition(s) of outcome(s): Pregnancy: Clinical, not defined Ongoing pregnancy: +FCM at 12 wks EGA Live birth: NR Multiples: Reported, but none occurred Complications: NR | | 3 | 49 | 52 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Klinkert, Broekmans, Looman, et al., 2005 #9240 | | | Definition(s) of outcome(s): Pregnancy: Clinical, not defined Ongoing pregnancy: +FCM at 12 wks EGA Live birth: NR Multiples: Reported, but none occurred Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Klinkert, Broekmans, Looman, et al., 2005 #9240 | | | Definition(s) of outcome(s): Pregnancy: Clinical, not defined Ongoing pregnancy: +FCM at 12 wks EGA Live birth: NR Multiples: Reported, but none occurred Complications: NR | Rel risk | 0.50 | 0.05 | 5.18 | Comments: Low power Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
3) No difference in total # of follicles, # oocytes, # embryos between grps.
Koicihi, Yukiko, Shima, et al., 2006 #53120 | Geographical location: Miyagi, Japan Study dates: Jan–Sep 2004 Size of population (no. of patients): 192 Number of cycles analyzed: 192 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - 3 weeks OCPs; - Randomized to; (a) Long protocol GnRH agonist (buserelin 900 microgram/day), with urinary human FSH daily.; (b) uhFSH until follicle diameter of 14 mm, then increased dose of uFSH to 300 IU/day and addition of GnRH antagonist (Citrorelix); (c) uhFSH until follicle diameter of 14 mm, dose decreased to 75 IU/day, Cetrorelix begun with 200 IU/day hCG.; - 10,000 IU hCG when 3 follicles 18mm; - maximum 2 embryos transferred | Age: Mean (SD): GnRH agonist: 32.3 (2.8); GnRH antagonist 32.6 (2.9); antagonist + hCG: 33.3 (3.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 21 (10.9%) Endometriosis: 8 (4.2%) Male factor: 91 (47.3%) Tubal factor: 58 (30.2) PCOS: Other (specify): Inclusion criteria:; - IVF/ICSI; - Age <40; - BMI < 27; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | 1) Clinical pregnancy (intention-to-treat), FSH + GnRH antagonist vs GnRH agonist long protocol: | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | | Preg + | Preg - | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | GnRH antagonist | 21 | 42 | 63 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | GnRH agonist | 33 | 33 | 66 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | | 54 | 75 | 129 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | | | Lower 95% CI | Upper 95 % CI | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | Rel risk | 0.67 | 0.44 | 1.02 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | 2) Clinical pregnancy (intention-to-treat), FSH + GnRH antagonist + hCG vs GnRH agonist long protocol: | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | | Preg + | Preg - | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | Antagonist + HCG | 23 | 40 | 63 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | GnRH agonist | 33 | 33 | 66 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | | 56 | 73 | 129 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | | | Lower 95% CI | Upper 95 % CI | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | Rel risk | 0.73 | 0.49 | 1.10 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | 3) Clinical pregnancy (intention-to-treat), FSH + GnRH antagonist + FSH vs GnRH antagonist + hCG: | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | | Preg + | Preg - | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | Antag + hCG | 23 | 40 | 63 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | Antag only | 21 | 42 | 63 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | | 44 | 82 | 126 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | | | Lower 95% CI | Upper 95 % CI | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Koicihi, Yukiko, Shima, et al., 2006 #53120 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy—gestational sac with FHR at 6 weeks Live birth: NR Multiples: NR Complications: Miscarriage | Rel risk | 1.10 | 0.68 | 1.77 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
4) Miscarriage rate higher in agonist long protocol (16.2%) vs 10.5 and 9.1%
Kolibianakis, Albano, Camus, et al., 2003 #14560 | Geographical location: Brussels, Belgium Study dates: May 2002 to January 2003 Size of population (no. of patients): 60 Number of cycles analyzed: 60 Number of cycles per patient: 1 Study type: RCT Interventions: GnRH antagonist starting either from day 1 or from day 6 of stimulation | Age: Mean (SD): 32 (0.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 65% Tubal factor: 18% Other: 17% Inclusion criteria: Age < 39 y, no more than three previous ART attempts, body-mass index between 18–29 kg/m2, regular menstrual cycles, no polycystic ovaries, no endometriosis or previous poor response to ovarian stimulation, and basal hormonal levels at initiation of stimulation (FSH < 10 IU/liter, LH < 10 IU/liter, E2 < 80 pg/ml, and progesterone (P) < 1.6 ng/ml) Exclusion criteria: None | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - (not clearly reported) Adequacy of randomization concealment: -
Kolibianakis, Albano, Camus, et al., 2003 #14560 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - (not clearly reported) Adequacy of randomization concealment: -
Kolibianakis, Albano, Camus, et al., 2003 #14560 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Day 6 | 15 | 15 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - (not clearly reported) Adequacy of randomization concealment: -
Kolibianakis, Albano, Camus, et al., 2003 #14560 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Day 1 | 14 | 16 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - (not clearly reported) Adequacy of randomization concealment: -
Kolibianakis, Albano, Camus, et al., 2003 #14560 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 29 | 31 | 60 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - (not clearly reported) Adequacy of randomization concealment: -
Kolibianakis, Albano, Camus, et al., 2003 #14560 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - (not clearly reported) Adequacy of randomization concealment: -
Rel risk | 1.07 | 0.63 | 1.81
Kolibianakis, Albano, Camus, et al., 2004 #12870 | Geographical location: Brussels, Belgium Study dates: May 2002 to April 2003 Size of population (no. of patients): 413 Number of cycles analyzed: 413 Number of cycles per patient: 1 Study type: RCT Interventions: Early-hCG: 10,000 IU of hCG either as soon as ≥3 follicles ≥17 mm were present on ultrasound Late-hCG: 2 days after this criterion was met | Age: Mean (SD): 32.5 (.03)* *not reported if this is SD or SEM; likely the latter. Race/ethnicity (n [%]): NR Diagnoses (n [%]): Endometriosis: [2%] Male factor: [62%] Tubal factor: [16%] PCOS: [4%] Other: [15%] Only %s reported Inclusion criteria: Age <39 years, presence of both ovaries, and basal levels of E2 (<80 pg/mL) and P (<1.6 ng/mL) at initiation of stimulation. Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Ongoing: pregnancy progressing beyond the 12^th^ week of gestation Multiples: Multiple ongoing pregnancy reported, not live birth Live birth: NR Multiples: Yes Complications: NR | 1) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Kolibianakis, Albano, Camus, et al., 2004 #12870 | | | | | Ongoing preg + | Ongoing preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Kolibianakis, Albano, Camus, et al., 2004 #12870 | | | | Early | 69 | 139 | 208 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Kolibianakis, Albano, Camus, et al., 2004 #12870 | | | | Late | 49 | 156 | 205 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Kolibianakis, Albano, Camus, et al., 2004 #12870 | | | | Total | 118 | 295 | 413 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Kolibianakis, Albano, Camus, et al., 2004 #12870 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Kolibianakis, Albano, Camus, et al., 2004 #12870 | | | | Rel risk | 1.39 | 1.02 | 1.89 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
2) Multiples: Sixteen twin pregnancies and one triplet pregnancy occurred in the early hCG group (multiple pregnancy rate, 24.6%) while 89 twin pregnancies occurred in the late-hCG group (multiple pregnancy rate, 18.4%).
Kolibianakis, Papanikolaou, Camus, et al., 2006 #53150 | Geographical location: Brussels, Belgium Study dates: May 2002 to December 2004 Size of population (no. of patients): 504 Number of cycles analyzed: 504 Number of cycles per patient: 1 Study type: RCT Interventions: OCP pretreatment: Low-dose monophasic combined OCP (150 μg desogestrel and 30 μg ethinylestradiol (Marvelon®; Organon), for 2 weeks starting on day 1 of the cycle. Non-OCP pretreatment: [Recombinant FSH was started on day 2 of the menstrual cycle in the non-OCP group or 5 days after discontinuation of the OCP in the OCP group at 200 IU per day.] | Age: Mean (SD): 31.2 ± 0.3 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Endometriosis: 3% Male factor: 62% Tubal factor: 16% Other - idiopathic 19% Inclusion criteria: Age < 39 years; ≤ 3 previous assisted reproduction (ART) attempts; body mass index (BMI) of 18–29 kg/m2; regular menstrual cycles; basal hormonal levels of FSH (<10 IU/l) and LH (<10 IU/l) at initiation of stimulation for the non-OCP group and at initiation of OCP in the OCP group. Exclusion criteria: Polycystic ovaries; endometriosis > stage II; previous poor response to ovarian stimulation. | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy was defined as pregnancy developing beyond 12 weeks. Live birth: NR Multiples: Yes (twins) Complications: Admission for hyperstimulation syndrome | 1) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Papanikolaou, Camus, et al., 2006 #53150 | | | | | Ongoing preg + | Ongoing preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Papanikolaou, Camus, et al., 2006 #53150 | | | | OCP | 51 | 199 | 250 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Papanikolaou, Camus, et al., 2006 #53150 | | | | Non-OCP | 60 | 194 | 254 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Papanikolaou, Camus, et al., 2006 #53150 | | | | Total | 111 | 393 | 504 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Papanikolaou, Camus, et al., 2006 #53150 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Papanikolaou, Camus, et al., 2006 #53150 | | | | Rel risk | 0.86 | 0.62 | 1.20 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Papanikolaou, Camus, et al., 2006 #53150 | | | | 2) Multiple births: Ongoing twin pregnancy rate of 17.8%, no difference between OCP (16.3%) and non-OCP (19%). | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
3) Complications: 4 patients in OCP and 1 in non-OCP group were admitted due to ovarian hyperstimulation syndrome.
Kolibianakis, Schultze-Mosgau, Schroer, et al., 2005 #39570 | Geographical location: Brussels, Belgium Lubeck, Germany Study dates: 12/03 – 10/04 Size of population: Grp 1: Surge with GnRH agonist-52 Grp 2: Surge with hCG-54 Number of cycles analyzed: 106 Number of cycles per patient: 1.0 Study type: RCT Interventions: Women undergoing IVF with a GnRH antagonist protocol were randomized to receive either GnRH agonist or hCG for final oocyte maturation. | Age: Mean (SD): Grp 1: 32.4 (0.6) Grp 2: 32.3 (0.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1: Unexplained infertility: 5 [9.6] Endometriosis: 0 Male factor: 36 [69.2] Tubal factor: 4 [7.7] PCOS: 0 Other: 7 [13.5] Grp 2 Unexplained infertility: 3 [5.6] Endometriosis: 0 Male factor: 40 [74.1] Tubal factor: 6 [11.1] PCOS: 0 Other: 5 [9.3] Inclusion criteria: ≥ 39, nl day 3 FSH, ≤ 3 previous ART cycles, BMI 18–29, regular cycles, no PCOS or hx of poor response, 2 ovaries, fresh sperm and no embryo biopsy Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Ongoing past 12 wks Live birth: NR Multiples: NR Complications: SAB | 1) Ongoing pg rate grp 1 vs 2: | | | | Comments: Powered to detect 30% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Kolibianakis, Schultze-Mosgau, Schroer, et al., 2005 #39570 | | | Definition(s) of outcome(s): Pregnancy: Ongoing past 12 wks Live birth: NR Multiples: NR Complications: SAB | | preg + | preg neg | Total | Comments: Powered to detect 30% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Kolibianakis, Schultze-Mosgau, Schroer, et al., 2005 #39570 | | | Definition(s) of outcome(s): Pregnancy: Ongoing past 12 wks Live birth: NR Multiples: NR Complications: SAB | GnRH | 2 | 50 | 52 | Comments: Powered to detect 30% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Kolibianakis, Schultze-Mosgau, Schroer, et al., 2005 #39570 | | | Definition(s) of outcome(s): Pregnancy: Ongoing past 12 wks Live birth: NR Multiples: NR Complications: SAB | hCG | 15 | 39 | 54 | Comments: Powered to detect 30% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Kolibianakis, Schultze-Mosgau, Schroer, et al., 2005 #39570 | | | Definition(s) of outcome(s): Pregnancy: Ongoing past 12 wks Live birth: NR Multiples: NR Complications: SAB | Total | 17 | 89 | 106 | Comments: Powered to detect 30% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Kolibianakis, Schultze-Mosgau, Schroer, et al., 2005 #39570 | | | Definition(s) of outcome(s): Pregnancy: Ongoing past 12 wks Live birth: NR Multiples: NR Complications: SAB | | Value | Lower 95% CI | Upper 95% CI | Comments: Powered to detect 30% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Kolibianakis, Schultze-Mosgau, Schroer, et al., 2005 #39570 | | | Definition(s) of outcome(s): Pregnancy: Ongoing past 12 wks Live birth: NR Multiples: NR Complications: SAB | Rel risk | 0.14 | 0.03 | 0.58 | Comments: Powered to detect 30% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Kolibianakis, Schultze-Mosgau, Schroer, et al., 2005 #39570 | | | Definition(s) of outcome(s): Pregnancy: Ongoing past 12 wks Live birth: NR Multiples: NR Complications: SAB | 2) SAB: | | | | Comments: Powered to detect 30% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Kolibianakis, Schultze-Mosgau, Schroer, et al., 2005 #39570 | | | Definition(s) of outcome(s): Pregnancy: Ongoing past 12 wks Live birth: NR Multiples: NR Complications: SAB | | SAB | No SAB | Total | Comments: Powered to detect 30% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Kolibianakis, Schultze-Mosgau, Schroer, et al., 2005 #39570 | | | Definition(s) of outcome(s): Pregnancy: Ongoing past 12 wks Live birth: NR Multiples: NR Complications: SAB | Grp 1 | 7 | 2 | 9 | Comments: Powered to detect 30% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Kolibianakis, Schultze-Mosgau, Schroer, et al., 2005 #39570 | | | Definition(s) of outcome(s): Pregnancy: Ongoing past 12 wks Live birth: NR Multiples: NR Complications: SAB | Grp 2 | 2 | 15 | 17 | Comments: Powered to detect 30% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Kolibianakis, Schultze-Mosgau, Schroer, et al., 2005 #39570 | | | Definition(s) of outcome(s): Pregnancy: Ongoing past 12 wks Live birth: NR Multiples: NR Complications: SAB | Total | 9 | 17 | 26 | Comments: Powered to detect 30% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Kolibianakis, Schultze-Mosgau, Schroer, et al., 2005 #39570 | | | Definition(s) of outcome(s): Pregnancy: Ongoing past 12 wks Live birth: NR Multiples: NR Complications: SAB | | Value | Lower 95% CI | Upper 95% CI | Comments: Powered to detect 30% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Rel risk | 6.61 | 1.72 | 25.45
Kolibianakis, Zikopoulos, Verpoest, et al., 2004 #10880 | Geographical location: Brussels, Belgium Study dates: Jan 2001–Dec 2003 Size of population (no. of patients): 460 Number of cycles analyzed: 460 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to day 3 or day 5 transfer at time of initial evaluation 1–2 embryos/transferred | Age: Mean (SD): Day 3: 31.3 (0.3); Day 5: 31.5 (0.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 16% Endometriosis: 5% Male factor: 65% Tubal factor: 10% PCOS: 3.5% Inclusion criteria:; - Age < 43 years; - Indication for IVF; Exclusion criteria:; - PGD; - Azoospermia | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: Yes (twins) Complications: NR | 1) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Zikopoulos, Verpoest, et al., 2004 #10880 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: Yes (twins) Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Zikopoulos, Verpoest, et al., 2004 #10880 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: Yes (twins) Complications: NR | Day 5 | 75 | 151 | 226 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Zikopoulos, Verpoest, et al., 2004 #10880 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: Yes (twins) Complications: NR | Day 3 | 75 | 159 | 234 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Zikopoulos, Verpoest, et al., 2004 #10880 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: Yes (twins) Complications: NR | | 150 | 310 | 460 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Zikopoulos, Verpoest, et al., 2004 #10880 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: Yes (twins) Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Zikopoulos, Verpoest, et al., 2004 #10880 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: Yes (twins) Complications: NR | Rel risk | 1.04 | 0.80 | 1.35 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Zikopoulos, Verpoest, et al., 2004 #10880 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: Yes (twins) Complications: NR | 2) Multiples (twins): | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Zikopoulos, Verpoest, et al., 2004 #10880 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: Yes (twins) Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Zikopoulos, Verpoest, et al., 2004 #10880 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: Yes (twins) Complications: NR | Day 5 | 20 | 55 | 75 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Zikopoulos, Verpoest, et al., 2004 #10880 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: Yes (twins) Complications: NR | Day 3 | 15 | 60 | 75 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Zikopoulos, Verpoest, et al., 2004 #10880 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: Yes (twins) Complications: NR | | 35 | 115 | 150 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kolibianakis, Zikopoulos, Verpoest, et al., 2004 #10880 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy beyond 12 weeks Live birth: NR Multiples: Yes (twins) Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 1.33 | 0.74 | 2.40
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | Geographical location: Athens, Greece Study dates: 2000–June 2005 Size of population (no. of patients): 115 Number of cycles analyzed: 115 (9 randomized subjects not included in analysis) Number of cycles per patient: 1.00 Study type: RCT Interventions:; - A: unilateral or bilateral laparoscopic salpingectomy; - B: proximal laparoscopic tubal occlusion (bilateral or unilateral); - C: No surgery; - All underwent long protocol COH with GnRH agonist, rFSH; - Groups A and B began 2 menstrual cycles after surgery | Age: Mean (SD): Salpingectomy: 31 (4.5); occlusion: 29.8 (3.4); control: error in table (reads "3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Tubal factor: 100% Inclusion criteria:; - Presence of unilateral or bilateral hydrosalpinges confirmed by hysterosalpingography;; - age of ≤41years; - suitability for IVF-intracytoplasmic sperm injection treatment, with FSH levels on females' cycle day 2–3 of ≤12 mIU/mL and available spermatozoa in semen; - no contraindication for laparoscopic surgery; no history of IVF attempts before recruitment; - absence of any other obvious pelvic pathology in females; Exclusion criteria: NR | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | 1) Ongoing pregnancy: any surgery vs control, intention-to-treat: | | | | Comments:; - No adjustment for multiple comparisons; - Rationale for sample size for control group not clear; Quality assessment: Randomization method: + Blinding: Dropout rate < 20%: Adequacy of randomization concealment: +
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | Surgery | 40 | 60 | 100
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | Control | 1 | 14 | 15
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | | 41 | 74 | 115
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | Rel risk | 6.00 | 0.89 | 40.47
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy, salpingectomy vs control, intention-to-treat:
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | Salpingectomy | 17 | 33 | 50
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | Control | 1 | 14 | 15
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | | 18 | 47 | 65
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | Rel risk | 5.10 | 0.74 | 35.23
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | 3) Ongoing pregnancy, occlusion vs control, intention-to-treat:
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | Occlusion | 23 | 27 | 50
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | Control | 1 | 14 | 15
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | | 24 | 41 | 65
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | Rel risk | 6.90 | 1.01 | 46.93
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | 4) Ongoing pregnancy, salpingectomy vs occlusion, intention-to-treat:
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | Salping-ectomy | 17 | 33 | 50
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | Occlusion | 23 | 27 | 50
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | | 40 | 60 | 100
Kontoravdis, Makrakis, Pantos, et al., 2006 #53180 | | | Definition(s) of outcome(s): Clinical pregnancy: Gestational sac 4 weeks after transfer Ongoing pregnancy: Beyond first trimester Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 0.74 | 0.45 | 1.21
Korosec, Virant-Klun, Tomazevic, et al., 2007 #71680 | Geographical location: Ljubljana, Slovenia Study dates: Apr 2004–June 2006 Size of population (no. of patients): 279 Number of cycles analyzed: 279 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to embryo transfer with hyaluronic acid containing media (EmbryoGlue®) vs. standard non-HA containing media All single blastocyst transfers | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 15% Endometriosis: 18% Male factor: 39% Tubal factor:43% Other: “Endocrine” Inclusion criteria:; - Age < 37; - 1^st^ 3 attempts; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy, fresh cycles: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Korosec, Virant-Klun, Tomazevic, et al., 2007 #71680 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg+ | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Korosec, Virant-Klun, Tomazevic, et al., 2007 #71680 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | HA | 12 | 16 | 28 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Korosec, Virant-Klun, Tomazevic, et al., 2007 #71680 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | No HA | 11 | 26 | 37 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Korosec, Virant-Klun, Tomazevic, et al., 2007 #71680 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 23 | 42 | 65 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Korosec, Virant-Klun, Tomazevic, et al., 2007 #71680 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Korosec, Virant-Klun, Tomazevic, et al., 2007 #71680 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.44 | 0.75 | 2.77 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Korosec, Virant-Klun, Tomazevic, et al., 2007 #71680 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 2) Pregnancy, frozen-thawed transfers: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Korosec, Virant-Klun, Tomazevic, et al., 2007 #71680 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Out + | Out - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Korosec, Virant-Klun, Tomazevic, et al., 2007 #71680 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | HA | 17 | 85 | 102 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Korosec, Virant-Klun, Tomazevic, et al., 2007 #71680 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | No HA | 17 | 95 | 112 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Korosec, Virant-Klun, Tomazevic, et al., 2007 #71680 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 34 | 180 | 214 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Korosec, Virant-Klun, Tomazevic, et al., 2007 #71680 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.10 | 0.59 | 2.03
Kosmas, Janssens, De Munck, et al., 2007 #71690 | Geographical location: Brussels, Belgium Study dates: Aug 2005–Feb 2006 Size of population (no. of patients): 300 Number of cycles analyzed: 300 Number of cycles per patient: 1.0 Study type: RCT Interventions: Single operator, ultrasound guided transfer vs. clinical touch | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 35 (11.7%) Endometriosis: 19 (6.3%) Male factor: 179 (59.7%) Tubal factor: 35 (11.7%) PCOS: 12(4.0%) Other: 36 (12.0%) Inclusion criteria:; - Age 40 or less; - BMI 20–30; - Fresh transfer; Exclusion criteria: Treatment of CIN | Definition(s) of outcome(s): Pregnancy: Rising hCG Clinical pregnancy—confirmed on ultrasound Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: 3 interim analyses, with no stated a priori stopping rules - described procedure not standard for stopping trial (original N = 700) Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Kosmas, Janssens, De Munck, et al., 2007 #71690 | | | Definition(s) of outcome(s): Pregnancy: Rising hCG Clinical pregnancy—confirmed on ultrasound Live birth: NR Multiples: NR Complications: NR | | Preg+ | Preg - | Total
Kosmas, Janssens, De Munck, et al., 2007 #71690 | | | Definition(s) of outcome(s): Pregnancy: Rising hCG Clinical pregnancy—confirmed on ultrasound Live birth: NR Multiples: NR Complications: NR | Ultra-sound | 63 | 87 | 150
Kosmas, Janssens, De Munck, et al., 2007 #71690 | | | Definition(s) of outcome(s): Pregnancy: Rising hCG Clinical pregnancy—confirmed on ultrasound Live birth: NR Multiples: NR Complications: NR | Clinical | 63 | 87 | 150
Kosmas, Janssens, De Munck, et al., 2007 #71690 | | | Definition(s) of outcome(s): Pregnancy: Rising hCG Clinical pregnancy—confirmed on ultrasound Live birth: NR Multiples: NR Complications: NR | Total | 126 | 174 | 300
Kosmas, Janssens, De Munck, et al., 2007 #71690 | | | Definition(s) of outcome(s): Pregnancy: Rising hCG Clinical pregnancy—confirmed on ultrasound Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.00 | 0.77 | 1.30
Latin-American Puregon IVF Study Group, 2001 #3580 | Geographical location: 15 sites in Argentina, Brazil, Chile, Colombia, Mexico, and Venezuela Study dates: June 1998–Sept 1999 Size of population (no. of patients): 404 Number of cycles analyzed: 404 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - Down-regulation with leuprolide; Randomized to 150 or 250 IU rFSH, fixed dosage; maximum duration of treatment 3 weeks rFSH started when E2 < 200 pg/ml, continued until at least 2 follicles ≥20 mm | Age: Mean (SD): 150 IU 35.1 (3.1); 250 IU 35.3 (2.9) Race/ethnicity (n [%]): Diagnoses (n [%]): Unexplained infertility: 47 (11.6%) Endometriosis: 17 (4.2%) Male factor: 177 (43.8%) Tubal factor: 97 (24.0%) PCOS: 0 Other (specify): Multiple: 66 (16.3%) Inclusion criteria:; - Ages 30–39; - Candidates for IVF/ICSI; - Normal menstrual cycles; - BMI 18–29; Exclusion criteria: Endocrine abnormality (PCOS, etc) ; 1 ovary or history of ovarian resection; severe endometriosis (grade III and IV); previous COH cycles in which less than three oocytes were retrieved; previous hospitalization due to the ovarian hyperstimulation syndrome (OHSS); chronic cardiovascular, hepatic, renal, or pulmonary disease; a history of (within 12 months) or current abuse of alcohol or drugs; administration of nonregistered investigational drugs within 3 months before screening. | Definition(s) of outcome(s): Pregnancy: Gestational sac with fetal heart rate Live birth: NR Multiples: NR Complications: OHSS | 1) Clinical pregnancy: | | | | Comments: Sample size based on # of cumulus-oocyte complexes, total dose rFSH Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Latin-American Puregon IVF Study Group, 2001 #3580 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with fetal heart rate Live birth: NR Multiples: NR Complications: OHSS | | Preg + | Preg - | | Comments: Sample size based on # of cumulus-oocyte complexes, total dose rFSH Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Latin-American Puregon IVF Study Group, 2001 #3580 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with fetal heart rate Live birth: NR Multiples: NR Complications: OHSS | 250 IU | 34 | 169 | 203 | Comments: Sample size based on # of cumulus-oocyte complexes, total dose rFSH Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Latin-American Puregon IVF Study Group, 2001 #3580 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with fetal heart rate Live birth: NR Multiples: NR Complications: OHSS | 150 IU | 34 | 167 | 201 | Comments: Sample size based on # of cumulus-oocyte complexes, total dose rFSH Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Latin-American Puregon IVF Study Group, 2001 #3580 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with fetal heart rate Live birth: NR Multiples: NR Complications: OHSS | | 68 | 336 | 404 | Comments: Sample size based on # of cumulus-oocyte complexes, total dose rFSH Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Latin-American Puregon IVF Study Group, 2001 #3580 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with fetal heart rate Live birth: NR Multiples: NR Complications: OHSS | | | Lower 95% CI | Upper 95 % CI | Comments: Sample size based on # of cumulus-oocyte complexes, total dose rFSH Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Latin-American Puregon IVF Study Group, 2001 #3580 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with fetal heart rate Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 0.99 | 0.64 | 1.53 | Comments: Sample size based on # of cumulus-oocyte complexes, total dose rFSH Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
2) 2 cases of hospitalized OHSS in 250 IU group, 0 in 150 IU group; overall OHSS 8 in 150 IU group, 5 in 250 IU group
Laverge, De Sutter, Van der Elst, et al., 2001 #5740 | Geographical location: Ghent, Belgium Study dates: NR Size of population (no. of patients): 746 Number of cycles analyzed: 746 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized after fertilization to (a) Day 2 transfer or (b) day 3 transfer 2 embryos transferred in patients <38 years; 3 if 2 failed cycles, age >38 years, or no good quality embryos | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Scheduled for IVF or ICSI ≥7 fertilized oocytes Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + hCG with gestational sac 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Laverge, De Sutter, Van der Elst, et al., 2001 #5740 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Scheduled for IVF or ICSI ≥7 fertilized oocytes Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + hCG with gestational sac 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Laverge, De Sutter, Van der Elst, et al., 2001 #5740 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Scheduled for IVF or ICSI ≥7 fertilized oocytes Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + hCG with gestational sac 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Day 2 | 166 | 208 | 374 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Laverge, De Sutter, Van der Elst, et al., 2001 #5740 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Scheduled for IVF or ICSI ≥7 fertilized oocytes Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + hCG with gestational sac 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Day 3 | 164 | 208 | 372 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Laverge, De Sutter, Van der Elst, et al., 2001 #5740 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Scheduled for IVF or ICSI ≥7 fertilized oocytes Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + hCG with gestational sac 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | 330 | 416 | 746 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Laverge, De Sutter, Van der Elst, et al., 2001 #5740 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Scheduled for IVF or ICSI ≥7 fertilized oocytes Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + hCG with gestational sac 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.01 | 0.86 | 1.18
Lee, Wu, Chen, et al., 2005 #40040 | Geographical location: Taipei, Taiwan Study dates: NR Size of population: Grp 1: 20 MD Grp 2: 20 SD Grp 3: 20 LP Number of cycles analyzed: 60 Number of cycles per patient: 1.0 Study type: RCT Interventions: MD: IVF with multiple doses of GnRH antagonist (cetrorelix) starting on day 5 SD: IVF with single dose of GnRH antagonist (cetrorelix) on day 7 LP: luteal phase GnRH agonist using nasal buserelin | Age: Grp 1: Mean (SD): 31.7 [3.8] Grp 2: Mean (SD): 32.9 [3.2] Grp 3 Mean (SD): 32.8 [4.4] Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1: Unexplained infertility: 1 [5] Endometriosis: 2 [10] Male factor: 7 [35] Tubal factor: 13 [65] PCOS: 0 Grp 2: Unexplained infertility: 2 [10] Endometriosis: 2 [10] Male factor: 11 [55] Tubal factor: 7 [35]] PCOS: 0 Grp 3: Unexplained infertility: 2 [10] Endometriosis: 2 [10] Male factor: 13 [65] Tubal factor: 6 [30] PCOS: 0 Inclusion criteria: ≤ 39, reg cycle 26–33 d, BMI 18–29, no hx of poor ovarian response, baseline FSH ≤ 10, nl liver and renal fx, 2 ovaries, no hormone tx within 3 mo Exclusion criteria: Women with ovarian factor, uterine factor infertility or presence of ovarian cysts | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | 1) Pg rate grp 1 vs 2: | | | | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | | pg pos | pg neg | Total | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | MD antagonist | 10 | 10 | 20 | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | SD antagonist | 5 | 15 | 20 | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | Total | 15 | 25 | 40 | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | Rel risk | 2.00 | 0.83 | 4.81 | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | 2) Pg rate grp 1 vs 3: | | | | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | | pg pos | pg neg | Total | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | MD antagonist | 10 | 10 | 20 | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | GnRH agonist | 9 | 11 | 20 | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | Total | 19 | 21 | 40 | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.11 | 0.58 | 2.14 | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | 3) P rate grp 2 vs 3: | | | | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | | pg pos | pg neg | Total | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | SD antagonist | 5 | 15 | 20 | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | GnRH agonist | 9 | 11 | 20 | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | Total | 14 | 26 | 40 | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Lee, Wu, Chen, et al., 2005 #40040 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Low numbers No adjustment for multiple comparisons Quality assessment: Randomization method: NR Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Rel risk | 0.56 | 0.23 | 1.37
Lenton, Soltan, Hewitt, et al., 2000 #7970 | Geographical location: Multicenters in UK Study dates: Jan 1997 – Feb 1998 Size of population: 168 Number of cycles analyzed: 155 Number of cycles per patient: 1.0 Study type: RCT Interventions: The study compares the usage of rFSH (follitropin alpha) vs. uFSH (urofollitropin HP) for ovulation induction for IVF or ICSI. | Age: Mean (SD):; - rFSH: 32.1 (2.9); - uFSH: 31.9 (3.5); Median: NR Range: 18–38 Race/ethnicity (n [%]): NR Diagnoses (%): Unexplained infertility:; - rFSH: 25.0; - uFSH: 22.7; Endometriosis:; - rFSH: 2.5; - uFSH: 2.7; Male factor:; - rFSH: 35; - uFSG: 47.7; Tubal factor:; - rFSH: 37.5; - uFSH: 45.3; Inclusion criteria:; - Tubal factor; - Gr I or II endometriosis; - 1^st^ cycle of ART; - Regular ovulatory menstrual cycle of 25d–35d; - BMI ≥ 18 but ≤ 26 kg/m^2^; - Presence of both ovaries; - Normal uterine cavity; - No gonadotropins in the month prior to the study; Exclusion criteria:; - Previous poor or hyper-response to gonadotropins; - Previous history of severer OHSS; - PCOS; - Male partner with azoospermia or clinical signs of infection detected in semen analysis within 12 mos | Definition(s) of outcome(s): Clinical Pregnancy: + gestational sac on u/s 28d after egg collection Live birth: Yes Multiples: NR Complications: Adverse events were recorded on the basis of the pt's or physician's observation An adverse event was classified as serious if it was fatal or life-threatening, was permanently disabling, required inpatient or prolonged hospitalization or was a congenital anomaly, cancer or overdose | 1) Positive pregnancy test: | | | | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | | Preg + | Preg - | Total | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | rFSH | 31 | 49 | 80 | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | uFSH | 27 | 48 | 75 | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | | 58 | 97 | 155 | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | Rel risk | 1.08 | 0.72 | 1.62 | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | 2) Clinical pregnancy rate: | | | | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | | Preg + | Preg - | Total | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | rFSH | 27 | 53 | 80 | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | uFSH | 24 | 51 | 75 | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | | 51 | 104 | 155 | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | Rel risk | 1.05 | 0.67 | 1.66 | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | 3) Live birth rate: | | | | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | | LB + | LB - | Total | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | rFSH | 27 | 53 | 80 | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | uFSH | 20 | 55 | 75 | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | | 47 | 108 | 155 | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | Rel risk | 1.27 | 0.78 | 2.06 | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | 4) Safety outcomes: | | | | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | Most adverse events were mild in nature. | | | | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | Of 50 pts, 25(30.9%) in rFSH and 26 (34.2%) in uFSh grp reported at lease one adverse event. | | | | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | Five pts had serious adverse events:; - 2 in rFSH (both OHSS); - 3 in uFSH (2 OHSS, one with iliac fossa pain) | | | | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | 13 pts had OHSS (7 from rFSH and 6 from uFSH | | | | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | Local tolerance: | | | | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | > 70% of pts reported either none or mild pain, tenderness, redness, itching, and bruising around the injection site | | | | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | 5) Pregnancy rate: | | | | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | No statistically significant differences between the 2 grps. | | | | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | Data reported on per- cycle and per-embryo-transfer basis. | | | | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Lenton, Soltan, Hewitt, et al., 2000 #7970 | | | | 6) Embryological characteristics of the two grps: | | | | Comments: Powered to detect difference in mean # of oocytes retreived Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
No statistically significant differences between the 2 grps.
Levi-Setti, Cavagna, and Bulletti, 2006 #53590 | Geographical location: Milan, Italy Study dates: NR Size of population (no. of patients): 40 Number of cycles analyzed: 40 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - Pretreated with OCPs; - On day 2, begin 225 IU/day rFSH; Cetrorelix 0.25 mg sc added when mean follicular diameter 14 mm; - Randomized to; (a) no additional treatment (225 IU rFSH alone); (b) 150 IU rFSH + 75 IU rLH | Age: Mean (SD): rFSH: 32.3 (2.3); rFSH + rLH: Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 100% Inclusion criteria:; - COH for ISCI for male factor; - normal cycles; - fresh ejaculated semen only; - Age < 37; - BMI <; - no previous pelvic surgery; - no evidence of endometriosis on U/S; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments : None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Levi-Setti, Cavagna, and Bulletti, 2006 #53590 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments : None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Levi-Setti, Cavagna, and Bulletti, 2006 #53590 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | rFSH + rLH | 7 | 13 | 20 | Comments : None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Levi-Setti, Cavagna, and Bulletti, 2006 #53590 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | rFSH only | 6 | 14 | 20 | Comments : None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Levi-Setti, Cavagna, and Bulletti, 2006 #53590 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 13 | 27 | 40 | Comments : None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Levi-Setti, Cavagna, and Bulletti, 2006 #53590 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments : None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.17 | 0.48 | 2.86
Levitas, Lunenfeld, Har-Vardi, et al., 2004 #13590 | Geographical location: Beer-Sheva, Israel Study dates: NR Size of population: Grp 1: 31 Grp 2: 23 Number of cycles analyzed: 54 Number of cycles per patient: 1.00 Study type: RCT Interventions: Women undergoing IVF/ICSI with history of 3 or more failed previous attempts Grp 1: Day 2–3 ET Grp 2: Blastocyst transfer | Age: Grp 1 Mean (SD): 31.2 (3.4) Grp 2: Mean (SD): 29.1 (3.1)) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1: Male factor: 19 [62.5] Tubal factor: 10 [33] Grp 2: Male factor: 18 [78.9]] Tubal factor: 5 [21.1] Inclusion criteria:; - Failure to conceive in at least 3 previous IVF cycles with acceptable ovarian response and fertilization; - Age < 37; - Normal uterine cavity; Exclusion criteria:; - Peak estradiol < 500 or retrieval of < 3 oocytes during previous IVF cycle | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | 1) Clinical pregnancy rate: | | | | Comments: Biases favoring pregnancy in Day 2–3 group include greater # of embryos transferred per cycle and greater # of pts receiving embryo transfer Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Levitas, Lunenfeld, Har-Vardi, et al., 2004 #13590 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg -
Levitas, Lunenfeld, Har-Vardi, et al., 2004 #13590 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | Blastocyst | 5 | 18 | 23
Levitas, Lunenfeld, Har-Vardi, et al., 2004 #13590 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | Day 2–3 | 4 | 31 | 35
Levitas, Lunenfeld, Har-Vardi, et al., 2004 #13590 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | | 9 | 49 | 58
Levitas, Lunenfeld, Har-Vardi, et al., 2004 #13590 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Levitas, Lunenfeld, Har-Vardi, et al., 2004 #13590 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | Rel risk | 1.90 | 0.57 | 6.35
Levitas, Lunenfeld, Har-Vardi, et al., 2004 #13590 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | 2) Multiple pregnancy:
Levitas, Lunenfeld, Har-Vardi, et al., 2004 #13590 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg -
Levitas, Lunenfeld, Har-Vardi, et al., 2004 #13590 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | Study drug | 2 | 3 | 5
Levitas, Lunenfeld, Har-Vardi, et al., 2004 #13590 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | Control | 3 | 1 | 4
Levitas, Lunenfeld, Har-Vardi, et al., 2004 #13590 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | | 5 | 4 | 9
Levitas, Lunenfeld, Har-Vardi, et al., 2004 #13590 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 0.53 | 0.16 | 1.79
Li, Lu, Hao, et al., 2005 #9590 | Geographical location: Peking, China Study dates: June 2001–June 2003 Size of population (no. of patients): 330 Number of cycles analyzed: 330 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - Embryo transfers 2–3 days after oocyte retrieval; - U/S group: transabdominal U/S using Wallace catheter; embryos transferred when catheter tip within 1.5–2.0 cm of fundus; - Controls: clinician judgment | Age (mean [SD]): U/S: 32.2 (3.9) Control: 32.5 (3.2) Race/ethnicity (n [%]): NR, assume 100% Asian Diagnoses (n [%]): Unexplained infertility: 24 (7.3%) Endometriosis: 42 (12.7%) Male factor: 125 (37.8%) Tubal factor: 123 (37.3%) Multiple diagnoses: 16 (4.8%) Inclusion criteria: Age 28–41, undergoing IVF or ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6–7 weeks (requirement for FHR not stated) Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: Relatively large discrepancy in group size Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Li, Lu, Hao, et al., 2005 #9590 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6–7 weeks (requirement for FHR not stated) Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: Relatively large discrepancy in group size Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Li, Lu, Hao, et al., 2005 #9590 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6–7 weeks (requirement for FHR not stated) Live birth: NR Multiples: NR Complications: NR | U/S | 66 | 112 | 178 | Comments: Relatively large discrepancy in group size Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Li, Lu, Hao, et al., 2005 #9590 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6–7 weeks (requirement for FHR not stated) Live birth: NR Multiples: NR Complications: NR | Control | 38 | 114 | 152 | Comments: Relatively large discrepancy in group size Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Li, Lu, Hao, et al., 2005 #9590 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6–7 weeks (requirement for FHR not stated) Live birth: NR Multiples: NR Complications: NR | | 104 | 226 | 330 | Comments: Relatively large discrepancy in group size Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Li, Lu, Hao, et al., 2005 #9590 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound at 6–7 weeks (requirement for FHR not stated) Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Relatively large discrepancy in group size Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.48 | 1.06 | 2.07
Lok, Chan, Chan, et al., 2002 #58340 | Geographical location: Hong Kong, China Study dates: Mar 2001–Aug 2001 Size of population (no. of patients): 106 Number of cycles analyzed: 106 Number of cycles per patient: 1.0 Study type: RCT Interventions: Patient-controlled sedation (PCS) vs. physician administered IV sedation | Age: Mean (SD): PCA: 32.9 (4.1) Physician controlled: 34.9 (3.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 20 (18%) Endometriosis: 7 (5%) Male factor: 10 (9%) Tubal factor: 61 (55%) PCOS: 7 (5%) Other: 1 (<1%) Inclusion criteria: Scheduled for oocyte retrieval Exclusion criteria:; - < 3 dominant follicles; - Contraindication to drugs used | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Lok, Chan, Chan, et al., 2002 #58340 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Lok, Chan, Chan, et al., 2002 #58340 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | Patient | 8 | 43 | 51 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Lok, Chan, Chan, et al., 2002 #58340 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | Physician | 13 | 42 | 55 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Lok, Chan, Chan, et al., 2002 #58340 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | Total | 21 | 85 | 106 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Lok, Chan, Chan, et al., 2002 #58340 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Lok, Chan, Chan, et al., 2002 #58340 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | Rel risk | 0.66 | 0.30 | 1.47 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
2) Pain scores higher with patient control, but overall satisfaction similar
Loutradis, Stefanidis, Drakakis, et al., 2004 #58350 | Geographical location: Chelmsford, MA Study dates: NR Size of population (no. of patients): 116 Number of cycles analyzed: 116 Number of cycles per patient: 1.0 Study type: RCT Interventions: Long-protocol GnRH agonist down-regulation (triptoreline) vs. GnRH antagonist (cetrorelix) | Age: Mean (SD): Agonist: 34.9 (4.7) Antagonist: 35.8 (4.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 20–38; - No low response in a previous treatment cycle; - No uterine or ovarian anomalies; - History of regular menstrual cycles ranging from 25 to 35 days; Exclusion criteria: Poor responder | Definition(s) of outcome(s): Pregnancy: Gestational sac at 4 weeks Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Loutradis, Stefanidis, Drakakis, et al., 2004 #58350 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 4 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Loutradis, Stefanidis, Drakakis, et al., 2004 #58350 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 4 weeks Live birth: NR Multiples: NR Complications: NR | Antagonist | 11 | 47 | 58 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Loutradis, Stefanidis, Drakakis, et al., 2004 #58350 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 4 weeks Live birth: NR Multiples: NR Complications: NR | Agonist | 14 | 44 | 58 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Loutradis, Stefanidis, Drakakis, et al., 2004 #58350 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 4 weeks Live birth: NR Multiples: NR Complications: NR | Total | 25 | 91 | 116 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Loutradis, Stefanidis, Drakakis, et al., 2004 #58350 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 4 weeks Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Rel risk | 0.79 | 0.39 | 1.58
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | Geographical location: Brussels, Belgium; Lubeck and Frankfurt, Germany Study dates: NR Size of population: 273 Number of cycles analyzed: 273 Number of cycles per patient: 1 Study type: RCT Interventions: Compared the use of GnRH agonist (buserelin) and GnRH antagonist (cetrorelix) in ovarian stimulation with HMG | Age: Mean (SD): Cetrorelix: 31.9 (3.7) Buserelin: 31.6 (3.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age ≤ 39; - Regular menstrual cycle ranging 24d–35d; - Normal ovarian function (detected by FSH ≤ 10 IU/L); - Normal ovarian morphology; - Normal uterus; - No more than three previous IVF or ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Clinical Pregnancy: u/s showed gestational sac and fetus with cardiac activity Live birth: NR Multiples: NR Complications: Miscarriage, ectopic pregnancies, OHSS using WHO criteria: OHSS II: Moderate OHSS III: Severe | 1) Clinical pregnancy rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Cetrorelix | 42 | 146 | 188 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Buserelin | 22 | 66 | 88 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | | 64 | 212 | 276 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Rel risk | 0.89 | 0.57 | 1.40 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | 2) Number of deliveries (patients): | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | | Del + | Del - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Cetrorelix | 34 | 154 | 188 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Busereln | 19 | 69 | 88 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | | 53 | 223 | 276 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Rel risk | 0.84 | 0.51 | 1.38 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | 3) Outcomes of all pregnancies: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | | [underlined: Cetrorelix] | [underlined: Buserelin] | [underlined: P-value] | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Clinical preg | 42 | 22 | NS | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Miscarriage | 7 | 2 | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Ectopic preg | 1 | 0 | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | No of deliveries | 34 | 19 | NS | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Singletons | 26 | 17 | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Twins | 8 | 2 | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | No. children born | 42 | 21 | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | 4) OHSS rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | | OHSS + | OHSS - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Cetrorelix | 2 | 186 | 188 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Buserelin | 5 | 80 | 85 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Total | 7 | 266 | 273 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | Rel risk | 0.18 | 0.04 | 0.91 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | 5) One pt in Buserelin group had severe OHSS | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ludwig, Felberbaum, Devroey, et al., 2000 #6990 (OHSS results only) and Albano, Felberbaum, Smitz, et al., 2000 #8590 | | | | 6) 3 (1.6%) pts in Cetrorelix and 6 (5.9%) in Buserelin grp did not get hCG trigger due to threatened OHSS. | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Significantly higher E2 on the date of hCG trigger was noted in Buserelin grp.
Ludwig, Finas, Katalinic, et al., 2001 #5200 | Geographical location: Lubeck, Germany Study dates: NR Size of population (no. of patients): 413 Number of cycles analyzed: 413 Number of cycles per patient: 1.0 Study type: RCT Interventions: COH by GnRH agonist long protocol; - Randomization stratified by OHSS risk; low risk (<12 oocytes, E2<2500 pg/mL day of retrieval); (a) 5000 IU hCG day of ET, 5000 IU 3 days later,2500 IU 6 days post-transfer; (b) 5000 IU hCG day of ET, vaginal progesterone 600mg/day from day prior to ET to menstrual bleeding or + hCG; (c) vaginal progesterone 600 mg/day High risk; (d) 5000 IU hCG day of ET, vaginal progesterone 600mg/day from day prior to ET to menstrual bleeding or + hCG; (e) vaginal progesterone 600 mg/day | Age: Mean (SD): 32.2 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40; - IVF/ICSI; Exclusion criteria:; - E2 > 5000 pg/ml; - Abdominal discomfort on day of ET | Definition(s) of outcome(s): Pregnancy: +FHR on ultrasound Live birth: Live or stillbirth > 500 g or live birth < 500 g Multiples: NR Complications: NR | 1) Clinical pregnancy, Progesterone only vs Progesterone + hCG (both high and low risk groups combined): | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ludwig, Finas, Katalinic, et al., 2001 #5200 | | Age: Mean (SD): 32.2 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40; - IVF/ICSI; Exclusion criteria:; - E2 > 5000 pg/ml; - Abdominal discomfort on day of ET | Definition(s) of outcome(s): Pregnancy: +FHR on ultrasound Live birth: Live or stillbirth > 500 g or live birth < 500 g Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ludwig, Finas, Katalinic, et al., 2001 #5200 | | Age: Mean (SD): 32.2 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40; - IVF/ICSI; Exclusion criteria:; - E2 > 5000 pg/ml; - Abdominal discomfort on day of ET | Definition(s) of outcome(s): Pregnancy: +FHR on ultrasound Live birth: Live or stillbirth > 500 g or live birth < 500 g Multiples: NR Complications: NR | Prog + hCG | 36 | 109 | 145 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ludwig, Finas, Katalinic, et al., 2001 #5200 | | Age: Mean (SD): 32.2 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40; - IVF/ICSI; Exclusion criteria:; - E2 > 5000 pg/ml; - Abdominal discomfort on day of ET | Definition(s) of outcome(s): Pregnancy: +FHR on ultrasound Live birth: Live or stillbirth > 500 g or live birth < 500 g Multiples: NR Complications: NR | Prog onlyl | 47 | 144 | 191 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ludwig, Finas, Katalinic, et al., 2001 #5200 | | Age: Mean (SD): 32.2 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40; - IVF/ICSI; Exclusion criteria:; - E2 > 5000 pg/ml; - Abdominal discomfort on day of ET | Definition(s) of outcome(s): Pregnancy: +FHR on ultrasound Live birth: Live or stillbirth > 500 g or live birth < 500 g Multiples: NR Complications: NR | | 83 | 253 | 336 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ludwig, Finas, Katalinic, et al., 2001 #5200 | | Age: Mean (SD): 32.2 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40; - IVF/ICSI; Exclusion criteria:; - E2 > 5000 pg/ml; - Abdominal discomfort on day of ET | Definition(s) of outcome(s): Pregnancy: +FHR on ultrasound Live birth: Live or stillbirth > 500 g or live birth < 500 g Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ludwig, Finas, Katalinic, et al., 2001 #5200 | | Age: Mean (SD): 32.2 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40; - IVF/ICSI; Exclusion criteria:; - E2 > 5000 pg/ml; - Abdominal discomfort on day of ET | Definition(s) of outcome(s): Pregnancy: +FHR on ultrasound Live birth: Live or stillbirth > 500 g or live birth < 500 g Multiples: NR Complications: NR | Rel risk | 1.01 | 0.69 | 1.47 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ludwig, Finas, Katalinic, et al., 2001 #5200 | | Age: Mean (SD): 32.2 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40; - IVF/ICSI; Exclusion criteria:; - E2 > 5000 pg/ml; - Abdominal discomfort on day of ET | Definition(s) of outcome(s): Pregnancy: +FHR on ultrasound Live birth: Live or stillbirth > 500 g or live birth < 500 g Multiples: NR Complications: NR | 2) Clinical pregnancy, progesterone only vs hCG only (high, low risk groups combined for progesterone only): | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ludwig, Finas, Katalinic, et al., 2001 #5200 | | Age: Mean (SD): 32.2 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40; - IVF/ICSI; Exclusion criteria:; - E2 > 5000 pg/ml; - Abdominal discomfort on day of ET | Definition(s) of outcome(s): Pregnancy: +FHR on ultrasound Live birth: Live or stillbirth > 500 g or live birth < 500 g Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ludwig, Finas, Katalinic, et al., 2001 #5200 | | Age: Mean (SD): 32.2 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40; - IVF/ICSI; Exclusion criteria:; - E2 > 5000 pg/ml; - Abdominal discomfort on day of ET | Definition(s) of outcome(s): Pregnancy: +FHR on ultrasound Live birth: Live or stillbirth > 500 g or live birth < 500 g Multiples: NR Complications: NR | hCG only | 15 | 62 | 77 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ludwig, Finas, Katalinic, et al., 2001 #5200 | | Age: Mean (SD): 32.2 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40; - IVF/ICSI; Exclusion criteria:; - E2 > 5000 pg/ml; - Abdominal discomfort on day of ET | Definition(s) of outcome(s): Pregnancy: +FHR on ultrasound Live birth: Live or stillbirth > 500 g or live birth < 500 g Multiples: NR Complications: NR | Prog only | 47 | 144 | 191 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ludwig, Finas, Katalinic, et al., 2001 #5200 | | Age: Mean (SD): 32.2 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40; - IVF/ICSI; Exclusion criteria:; - E2 > 5000 pg/ml; - Abdominal discomfort on day of ET | Definition(s) of outcome(s): Pregnancy: +FHR on ultrasound Live birth: Live or stillbirth > 500 g or live birth < 500 g Multiples: NR Complications: NR | | 62 | 206 | 268 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ludwig, Finas, Katalinic, et al., 2001 #5200 | | Age: Mean (SD): 32.2 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40; - IVF/ICSI; Exclusion criteria:; - E2 > 5000 pg/ml; - Abdominal discomfort on day of ET | Definition(s) of outcome(s): Pregnancy: +FHR on ultrasound Live birth: Live or stillbirth > 500 g or live birth < 500 g Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ludwig, Finas, Katalinic, et al., 2001 #5200 | | Age: Mean (SD): 32.2 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40; - IVF/ICSI; Exclusion criteria:; - E2 > 5000 pg/ml; - Abdominal discomfort on day of ET | Definition(s) of outcome(s): Pregnancy: +FHR on ultrasound Live birth: Live or stillbirth > 500 g or live birth < 500 g Multiples: NR Complications: NR | Rel risk | 0.79 | 0.47 | 1.33 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
3) Similar results for ongoing pregnancy
Ludwig, Schwartz, Babahan, et al., 2002 #1940 | Geographical location: Lubeck, Germany Study dates: NR Size of population (no. of patients): 126 Number of cycles analyzed: 126 Number of cycles per patient: 1.0 Study type: RCT Interventions: Vaginal progesterone (a) 8 % gel once daily or (b) 200 mg capsule 3×/daily, beginning day before ET Long prototol GnRH agonist COH | Age: Mean (SD): Gel: 31.4 (5.5) ; capsules: 31.5 (4.3)acoss 5 groups—no significant differences Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF/ICSI Exclusion criteria: Estradiol <2000 pg/mL day of retrieval | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR Ongoing pregnancy: > 12 weeks Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments:; - Randomization method not described; - Relatively large discrepancy between arms; Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Ludwig, Schwartz, Babahan, et al., 2002 #1940 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR Ongoing pregnancy: > 12 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Ludwig, Schwartz, Babahan, et al., 2002 #1940 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR Ongoing pregnancy: > 12 weeks Live birth: NR Multiples: NR Complications: NR | Gel | 21 | 52 | 73
Ludwig, Schwartz, Babahan, et al., 2002 #1940 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR Ongoing pregnancy: > 12 weeks Live birth: NR Multiples: NR Complications: NR | Capsule | 10 | 43 | 53
Ludwig, Schwartz, Babahan, et al., 2002 #1940 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR Ongoing pregnancy: > 12 weeks Live birth: NR Multiples: NR Complications: NR | | 31 | 95 | 126
Ludwig, Schwartz, Babahan, et al., 2002 #1940 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR Ongoing pregnancy: > 12 weeks Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Ludwig, Schwartz, Babahan, et al., 2002 #1940 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR Ongoing pregnancy: > 12 weeks Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.52 | 0.78 | 2.96
Ludwig, Schwartz, Babahan, et al., 2002 #1940 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR Ongoing pregnancy: > 12 weeks Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy:
Ludwig, Schwartz, Babahan, et al., 2002 #1940 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR Ongoing pregnancy: > 12 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Ludwig, Schwartz, Babahan, et al., 2002 #1940 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR Ongoing pregnancy: > 12 weeks Live birth: NR Multiples: NR Complications: NR | Study drug | 18 | 55 | 73
Ludwig, Schwartz, Babahan, et al., 2002 #1940 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR Ongoing pregnancy: > 12 weeks Live birth: NR Multiples: NR Complications: NR | Control | 9 | 44 | 53
Ludwig, Schwartz, Babahan, et al., 2002 #1940 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR Ongoing pregnancy: > 12 weeks Live birth: NR Multiples: NR Complications: NR | | 27 | 99 | 126
Ludwig, Schwartz, Babahan, et al., 2002 #1940 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR Ongoing pregnancy: > 12 weeks Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 1.45 | 0.71 | 2.98
Lukassen, Braat, Wetzels, et al., 2005 #9180 | Geographical location: Nijmegen, Netherlands Study dates: Jan 2001 – Feb 2003 Size of population: Grp 1: 54 Grp 2: 53 Number of cycles analyzed: 14 Number of cycles per patient: 1.37 Study type: RCT Interventions: Grp 1: 2 IVF/ICSI cycles with single embryo transfer Grp 2: 1 IVF/ICSI cycle with double embryo transfer IVF/ICSI with luteal phase GnRH downregulation and rFSH stimulation | Age: Grp 1 Mean (SD): 30.2 (3.2) Range: 20–34 Grp 2: Mean (SD): 31.2 )2.9) Range: 25–34 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1 Unexplained infertility: 5 [9] Male factor: 36 [67] Tubal factor: 5 [9] “Other female”: 8 [15] Grp 2 Unexplained infertility:14[ [27] Male factor: 26 [49] Tubal factor: 9 [17] “Other female”: 4 [8] Inclusion criteria:; - Age < 35; - Basal FSH < 10; - First IVF/ICSI attempt ever or after successful pregnancy; - At least 2 embryos (1 grade 4 and 1 at least grader 3) available for transfer on day 3; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | 1) Clinical pregnancy rate: | | | | Comments:; - 4 pts did not undergo 2^nd^ cycle in Grp 1; - 3 pts received 2 embryos during 2^nd^ cycle of Grp 1; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | | Preg + | Preg - | Total
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | Grp 1 | 30 | 24 | 54
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | Grp 2 | 25 | 28 | 53
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | Total | 55 | 52 | 107
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 1.18 | 0.81 | 1.71
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | 2) Live birth:
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | | LB + | LB - | Total
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | Grp 1 | 22 | 32 | 54
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | Grp 2 | 19 | 34 | 53
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | Total | 41 | 66 | 107
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 1.14 | 0.70 | 1.84
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | 3) Multiples:
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | | Multi + | Multi - | Total
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | Grp 1 | 0 | 22 | 22
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | Grp 2 | 7 | 12 | 19
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | Total | 7 | 34 | 41
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Lukassen, Braat, Wetzels, et al., 2005 #9180 | | | Definition(s) of outcome(s): Pregnancy: + FCM Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 0.06 | 0.00 | 0.95
4) Costs per live birth similar (; 13,438 for SET,; 13,680 for DET)
Lukaszuk, Liss, Lukaszuk, et al., 2005 #40480 | Geographical location: Gdansk, Poland Study dates: Mar 2002–Mar 2003 Size of population (no. of patients): 166 Number of cycles analyzed: 231 Number of cycles per patient: 1.39 Study type: RCT Interventions: From day of transfer, randomized to; (a) 600 mg vaginal progesterone (capsules); (b) 2 mg estradiol daily; (c) 6 mg estradiol daily | Age: Mean (SD): P only: 32.1 (4.5); P + 2 mg E2: 31.7 (3.9); P + 6 mg E2: 31.1 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 19 (11.4%) Endometriosis: 6 (3.6%) Male factor: 66 (39.8%) Tubal factor: 36 (21.7%) PCOS: 20 (12.1%) Other: Mixed: 19 (11.4%) Inclusion criteria:; - < 40 years; - ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac at 5 weeks 2 days Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy per randomized patient, P only vs P + 2 mg E2: | | | | Comments:; - Unclear if randomized to same treatment for multiple cycles—Table 1 suggests this was the case, but not explicitly described; - Randomization method not described; - Relatively large imbalance in patient numbers by group; No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Lukaszuk, Liss, Lukaszuk, et al., 2005 #40480 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 5 weeks 2 days Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Lukaszuk, Liss, Lukaszuk, et al., 2005 #40480 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 5 weeks 2 days Live birth: NR Multiples: NR Complications: NR | P + 2 mg E2 | 24 | 23 | 47
Lukaszuk, Liss, Lukaszuk, et al., 2005 #40480 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 5 weeks 2 days Live birth: NR Multiples: NR Complications: NR | P only | 18 | 32 | 50
Lukaszuk, Liss, Lukaszuk, et al., 2005 #40480 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 5 weeks 2 days Live birth: NR Multiples: NR Complications: NR | | 42 | 55 | 97
Lukaszuk, Liss, Lukaszuk, et al., 2005 #40480 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 5 weeks 2 days Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Lukaszuk, Liss, Lukaszuk, et al., 2005 #40480 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 5 weeks 2 days Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.42 | 0.89 | 2.26
Lukaszuk, Liss, Lukaszuk, et al., 2005 #40480 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 5 weeks 2 days Live birth: NR Multiples: NR Complications: NR | 2) Pregnancy per randomized patient, P only vs P + 6 mg E2:
Lukaszuk, Liss, Lukaszuk, et al., 2005 #40480 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 5 weeks 2 days Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Lukaszuk, Liss, Lukaszuk, et al., 2005 #40480 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 5 weeks 2 days Live birth: NR Multiples: NR Complications: NR | P + 6 mg E2 | 40 | 29 | 69
Lukaszuk, Liss, Lukaszuk, et al., 2005 #40480 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 5 weeks 2 days Live birth: NR Multiples: NR Complications: NR | P only | 18 | 32 | 50
Lukaszuk, Liss, Lukaszuk, et al., 2005 #40480 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 5 weeks 2 days Live birth: NR Multiples: NR Complications: NR | | 58 | 61 | 119
Lukaszuk, Liss, Lukaszuk, et al., 2005 #40480 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 5 weeks 2 days Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Lukaszuk, Liss, Lukaszuk, et al., 2005 #40480 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac at 5 weeks 2 days Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.61 | 1.06 | 2.45
3) Pregnancy 6 mg E2 vs 2 mg E2: 1.14 (0.80, 1.60); Multiple pregnancies significantly higher with E2 regimens (0% P only, 30.4% 2 mg E2, 25.6% 6 mg E2)
Ma, Rowe, and Yuen, 2006 #53850 | Geographical location: Vancouver, Canada Study dates: 1999-2003 Size of population (no. of patients): 172 Number of cycles analyzed: 172 (14 excluded because of few oocytes) Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to; (a) control or; (b) assisted hatching with acidic Tyrode's solution day 3 prior to transfer | Age: Mean (SD): Control: 35.5 (3.8); assisted hatching 35.4 (4.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - semen analysis with fewer than 1 × 10^6^ sperm/mL with <50% progressively motile sperm (grade 3) or<5% normal sperm morphology (Kruger's criteria); - ≥ 1 failed IVF cycle with an adequate number of inseminated oocytes or with a fertilization rate of <20%.; Exclusion criteria: Retrieval of fewer than 4 oocytes and a baseline serum FSH of <12 IU/mL. | Definition(s) of outcome(s): Pregnancy: Intrauterine gestational sac at 5 weeks Live birth: Yes Multiples: Yes Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ma, Rowe, and Yuen, 2006 #53850 | | | Definition(s) of outcome(s): Pregnancy: Intrauterine gestational sac at 5 weeks Live birth: Yes Multiples: Yes Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ma, Rowe, and Yuen, 2006 #53850 | | | Definition(s) of outcome(s): Pregnancy: Intrauterine gestational sac at 5 weeks Live birth: Yes Multiples: Yes Complications: NR | Assisted hatching | 29 | 56 | 85 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ma, Rowe, and Yuen, 2006 #53850 | | | Definition(s) of outcome(s): Pregnancy: Intrauterine gestational sac at 5 weeks Live birth: Yes Multiples: Yes Complications: NR | Control | 18 | 65 | 83 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ma, Rowe, and Yuen, 2006 #53850 | | | Definition(s) of outcome(s): Pregnancy: Intrauterine gestational sac at 5 weeks Live birth: Yes Multiples: Yes Complications: NR | | 47 | 121 | 168 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ma, Rowe, and Yuen, 2006 #53850 | | | Definition(s) of outcome(s): Pregnancy: Intrauterine gestational sac at 5 weeks Live birth: Yes Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ma, Rowe, and Yuen, 2006 #53850 | | | Definition(s) of outcome(s): Pregnancy: Intrauterine gestational sac at 5 weeks Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 1.57 | 0.95 | 2.61 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ma, Rowe, and Yuen, 2006 #53850 | | | Definition(s) of outcome(s): Pregnancy: Intrauterine gestational sac at 5 weeks Live birth: Yes Multiples: Yes Complications: NR | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ma, Rowe, and Yuen, 2006 #53850 | | | Definition(s) of outcome(s): Pregnancy: Intrauterine gestational sac at 5 weeks Live birth: Yes Multiples: Yes Complications: NR | | Birth + | Birth - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ma, Rowe, and Yuen, 2006 #53850 | | | Definition(s) of outcome(s): Pregnancy: Intrauterine gestational sac at 5 weeks Live birth: Yes Multiples: Yes Complications: NR | Assisted hatching | 20 | 65 | 85 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ma, Rowe, and Yuen, 2006 #53850 | | | Definition(s) of outcome(s): Pregnancy: Intrauterine gestational sac at 5 weeks Live birth: Yes Multiples: Yes Complications: NR | Control | 15 | 68 | 83 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ma, Rowe, and Yuen, 2006 #53850 | | | Definition(s) of outcome(s): Pregnancy: Intrauterine gestational sac at 5 weeks Live birth: Yes Multiples: Yes Complications: NR | | 35 | 133 | 168 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ma, Rowe, and Yuen, 2006 #53850 | | | Definition(s) of outcome(s): Pregnancy: Intrauterine gestational sac at 5 weeks Live birth: Yes Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ma, Rowe, and Yuen, 2006 #53850 | | | Definition(s) of outcome(s): Pregnancy: Intrauterine gestational sac at 5 weeks Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 1.30 | 0.72 | 2.37 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
3) Multiple pregnancy hatching vs control 1.5 (0.65, 1.47); implantation rate significantly higher with hatching (16% vs 8%)
Mahani and Davar, 2007 #71900 | Geographical location: Kerman, Iran Study dates: Sep 2003–Jan 2004 Size of population (no. of patients): 60 Number of cycles analyzed: 60 Number of cycles per patient: 1.0 Study type: RCT Interventions: Embryo transfer with media with hyaluronic acid vs. media with albumin | Age: Mean (SD): HA: 27.5 (4.3) Albumin: 28.6 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 35 (58.3%) Tubal factor: 16 (26.7%) PCOS: 9 (15%) Inclusion criteria:; - Age ≤ 35 years; - At least 3 embryos for transfer; - No previous IVF; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mahani and Davar, 2007 #71900 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mahani and Davar, 2007 #71900 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | HA | 11 | 19 | 30 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mahani and Davar, 2007 #71900 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Albumin | 7 | 23 | 30 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mahani and Davar, 2007 #71900 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Total | 18 | 42 | 60 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mahani and Davar, 2007 #71900 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mahani and Davar, 2007 #71900 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.57 | 0.71 | 3.50 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mahani and Davar, 2007 #71900 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy: | | | | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mahani and Davar, 2007 #71900 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mahani and Davar, 2007 #71900 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | HA | 9 | 21 | 30 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mahani and Davar, 2007 #71900 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Albumin | 5 | 25 | 30 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mahani and Davar, 2007 #71900 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Total | 14 | 46 | 60 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mahani and Davar, 2007 #71900 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 1.80 | 0.68 | 4.74
Makrakis, Angeli, Agapitou, et al., 2006 #53910 | Geographical location: Athens, Greece Study dates: Sep 2002–April 2005 Size of population (no. of patients): 316 Number of cycles analyzed: 316 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to assisted hatching on day 3 with; (a) laser or; (b) mechanical method | Age: Mean (SD): Mechanical: 40.9 (1.5) Laser: 41.0 (1.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - advanced age (≥39 years),; - primary infertility; - no previous application of ART; - decision for IVF treatment; - embryos available for transfer; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac on ultrasound Viable pregnancy: pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Makrakis, Angeli, Agapitou, et al., 2006 #53910 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac on ultrasound Viable pregnancy: pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Makrakis, Angeli, Agapitou, et al., 2006 #53910 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac on ultrasound Viable pregnancy: pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: NR | Mechanical | 33 | 125 | 158 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Makrakis, Angeli, Agapitou, et al., 2006 #53910 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac on ultrasound Viable pregnancy: pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: NR | Laser | 43 | 115 | 158 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Makrakis, Angeli, Agapitou, et al., 2006 #53910 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac on ultrasound Viable pregnancy: pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: NR | | 76 | 240 | 316 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Makrakis, Angeli, Agapitou, et al., 2006 #53910 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac on ultrasound Viable pregnancy: pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Makrakis, Angeli, Agapitou, et al., 2006 #53910 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac on ultrasound Viable pregnancy: pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.77 | 0.52 | 1.14 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Makrakis, Angeli, Agapitou, et al., 2006 #53910 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac on ultrasound Viable pregnancy: pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: NR | 2) Viable pregnancy: | | | | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Makrakis, Angeli, Agapitou, et al., 2006 #53910 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac on ultrasound Viable pregnancy: pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Makrakis, Angeli, Agapitou, et al., 2006 #53910 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac on ultrasound Viable pregnancy: pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: NR | Mechanical | 31 | 127 | 158 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Makrakis, Angeli, Agapitou, et al., 2006 #53910 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac on ultrasound Viable pregnancy: pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: NR | Laser | 37 | 121 | 158 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Makrakis, Angeli, Agapitou, et al., 2006 #53910 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac on ultrasound Viable pregnancy: pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: NR | | 68 | 248 | 316 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Makrakis, Angeli, Agapitou, et al., 2006 #53910 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac on ultrasound Viable pregnancy: pregnancy beyond 12 weeks Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Rel risk | 0.84 | 0.55 | 1.28
Malmusi, La Marca, Giulini, et al., 2005 #40280 | Geographical location: Modena, Italy Study dates: NR Size of population: Grp 1: 30-GnRH a Grp 2: 25- GnRH antagonist Number of cycles analyzed: 55 Number of cycles per patient: 1.00 Study type: RCT Interventions: Women undergoing ICSI with a hx of previous poor response were randomized to use of a GnRH agonist flare vs GnRH antagonist protocol GnRH agonist received 0.1 mg triptorelin on cycle day 1. GnRH antagonist grp received 0.25 mg ganirelix when lead follicle reached 14 mm | Age: Grp 1 Mean (SD): 36.6 [0.8] Grp 2 Mean (SD): 36.2 [1.2] Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: NR Endometriosis: NR Male factor: NR Tubal factor: NR PCOS: NR Inclusion criteria: Hx of poor response defined as no ovarian response with ≥ 300 IU rFSH for ≥ 15 d or less than 5 oocytes retrieved. FSH < 15. Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: defined as sac on USD Live birth: NR Multiples: NR Complications: NR | 1) Pg rate grp 1 vs 2: | | | | Comments: Low power Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Malmusi, La Marca, Giulini, et al., 2005 #40280 | | | Definition(s) of outcome(s): Pregnancy: defined as sac on USD Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: Low power Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Malmusi, La Marca, Giulini, et al., 2005 #40280 | | | Definition(s) of outcome(s): Pregnancy: defined as sac on USD Live birth: NR Multiples: NR Complications: NR | Study drug | 3 | 22 | 25 | Comments: Low power Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Malmusi, La Marca, Giulini, et al., 2005 #40280 | | | Definition(s) of outcome(s): Pregnancy: defined as sac on USD Live birth: NR Multiples: NR Complications: NR | Control | 6 | 24 | 30 | Comments: Low power Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Malmusi, La Marca, Giulini, et al., 2005 #40280 | | | Definition(s) of outcome(s): Pregnancy: defined as sac on USD Live birth: NR Multiples: NR Complications: NR | | 9 | 46 | 55 | Comments: Low power Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Malmusi, La Marca, Giulini, et al., 2005 #40280 | | | Definition(s) of outcome(s): Pregnancy: defined as sac on USD Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Low power Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Rel risk | 0.60 | 0.17 | 2.16
Mamas, 2006 #53940 | Geographical location: Athens, Greece Study dates: July 2002 to December 2004 Size of population (no. of patients): 276 Number of cycles analyzed: 403 Number of cycles per patient: 1.45 Study type: RCT Interventions: FSP: Fallopian tube sperm perfusion IUTPI: Intrauterine tuboperitoneal insemination | Age: Mean (SD): 33 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Other (specify): “All couples suffered from unexplained infertility, mild or moderate male infertility, or mild or moderate endometriosis after treatment.” Inclusion criteria: Women with age < 40 years, regular menstrual cycle of 25–33 days, spontaneous ovulation by vaginal ultrasound and normal serum progesterone concentrations (> 10 ng/mL) in midluteal phase serum, serum FSH <10 U/L on day 3, LH, PRL, T, sex hormone-binding globulin, and thyroid hormone concentrations in the normal range, negative chlamydia detection tests, body mass index between 20 and 29 kg/m2, and male with inseminate motile sperm count (IMC) recovered after gradients > 10^6^ Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: OHSS | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mamas, 2006 #53940 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: OHSS | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mamas, 2006 #53940 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: OHSS | IUTPI | 60 | 78 | 138 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mamas, 2006 #53940 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: OHSS | FSP | 35 | 103 | 138 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mamas, 2006 #53940 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: OHSS | | 95 | 181 | 276 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mamas, 2006 #53940 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: OHSS | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mamas, 2006 #53940 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: OHSS | Rel risk | 1.71 | 1.22 | 2.42 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mamas, 2006 #53940 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: Yes Complications: OHSS | 2) Three twin pregnancies in FSP and 5 in IUTPI (plus 1 quintuplets reduced to twins) | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
3) Three cases of mild ovarian hyperstimulation syndrome (OHSS) in both groups, no severe OHSS.
Manau, Fabregues, Arroyo, et al., 2002 #58370 | Geographical location: Barcelona, Spain Study dates: NR Size of population (no. of patients): 30 Number of cycles analyzed: 30 Number of cycles per patient: 1.0 Study type: RCT Interventions: Long protocol GnRH agonist, rFSH for COH, randomized to; (a) hCG or; (b) rLH for follicular maturation | Age: Mean (SD): hCG: 33.2 (0.9) LH: 32.6 (0.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 7 (23%) Endometriosis: 1 (3%) Male factor: 17 (57%) Tubal factor: 5 (17%) Inclusion criteria:; - Age 27–37; - Regular menses; - FSH < 12; Exclusion criteria:; - PCOS; - > 2 previous attempts | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Manau, Fabregues, Arroyo, et al., 2002 #58370 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Manau, Fabregues, Arroyo, et al., 2002 #58370 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | rLH | 9 | 6 | 15 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Manau, Fabregues, Arroyo, et al., 2002 #58370 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | hCG | 9 | 6 | 15 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Manau, Fabregues, Arroyo, et al., 2002 #58370 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | Total | 18 | 12 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Manau, Fabregues, Arroyo, et al., 2002 #58370 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Manau, Fabregues, Arroyo, et al., 2002 #58370 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 1.00 | 0.56 | 1.79 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Manau, Fabregues, Arroyo, et al., 2002 #58370 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | 2) OHSS: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Manau, Fabregues, Arroyo, et al., 2002 #58370 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | | OHSS + | OHSS - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Manau, Fabregues, Arroyo, et al., 2002 #58370 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | rLH | 0 | 15 | 15 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Manau, Fabregues, Arroyo, et al., 2002 #58370 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | hCG | 2 | 13 | 15 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Manau, Fabregues, Arroyo, et al., 2002 #58370 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | Total | 2 | 28 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Manau, Fabregues, Arroyo, et al., 2002 #58370 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.20 | 0.01 | 3.85
Marci, Caserta, Dolo, et al., 2005 #58380 | Geographical location: L'Aquila, Italy Study dates: Jan 2001–Dec 2002 Size of population (no. of patients): 60 Number of cycles analyzed: 60 Number of cycles per patient: 1.0 Study type: RCT Interventions: GnRH agonist vs. antagonist (Cetrorelix) | Age: Mean (SD): Agonist: 39.0 (3.1) Antagonist: 38.8 (2.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age 32–44; - Estradiol concentrations < 600 pg/nil on the day of HCG administration; - Poor response (number of oocyte retrieved < 3) after a previous standard long protocol using analogues for down regulation and recombinant gonadotrophin at a dose of 225 lU for stimulation; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28–35 days after transfer Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Marci, Caserta, Dolo, et al., 2005 #58380 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28–35 days after transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Marci, Caserta, Dolo, et al., 2005 #58380 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28–35 days after transfer Live birth: NR Multiples: NR Complications: NR | Antagonist | 5 | 25 | 30 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Marci, Caserta, Dolo, et al., 2005 #58380 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28–35 days after transfer Live birth: NR Multiples: NR Complications: NR | Agonist | 2 | 28 | 30 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Marci, Caserta, Dolo, et al., 2005 #58380 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28–35 days after transfer Live birth: NR Multiples: NR Complications: NR | Total | 7 | 53 | 60 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Marci, Caserta, Dolo, et al., 2005 #58380 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28–35 days after transfer Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Marci, Caserta, Dolo, et al., 2005 #58380 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28–35 days after transfer Live birth: NR Multiples: NR Complications: NR | Rel risk | 2.50 | 0.53 | 11.89 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Marci, Caserta, Dolo, et al., 2005 #58380 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28–35 days after transfer Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy: | | | | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Marci, Caserta, Dolo, et al., 2005 #58380 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28–35 days after transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Marci, Caserta, Dolo, et al., 2005 #58380 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28–35 days after transfer Live birth: NR Multiples: NR Complications: NR | Antagonist | 4 | 26 | 30 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Marci, Caserta, Dolo, et al., 2005 #58380 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28–35 days after transfer Live birth: NR Multiples: NR Complications: NR | Agonist | 0 | 30 | 30 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Marci, Caserta, Dolo, et al., 2005 #58380 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28–35 days after transfer Live birth: NR Multiples: NR Complications: NR | Total | 4 | 56 | 60 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Marci, Caserta, Dolo, et al., 2005 #58380 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28–35 days after transfer Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 9.00 | 0.51 | 160.18
Marrs, Meldrum, Muasher, et al., 2004 #13850 | Geographical location: ReDondo Beach, CA Study dates: NR Size of population: Grp 1: 212 Grp 2: 219 Number of cycles analyzed: 431 Number of cycles per patient: 1.0 Study type: RCT Interventions: ICSI cycles with luteal phase GnRH and rFSH Up to 3 embryos transferred. Grp 1: 150 IU rLH starting stim day 6 + rFSH Grp 2: rFSH only | Age: Grp 1 Mean (SD): 32.4 (3.8) Grp 2 Mean (SD): 31.9 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Normo-ovulatory; - Age 18–40; - FSH < 11.3; - Both ovaries present; - Male factor infertility requiring ICSI; Exclusion criteria:; - More than 2 previous ICSI cycles; - Smoking > 10/day; - LH/FSH > 2; - Systemic disease | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: Higher # of embryos transferred in Grp 1: 2.9 vs. 2.8, P = 0.04 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Marrs, Meldrum, Muasher, et al., 2004 #13850 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: Higher # of embryos transferred in Grp 1: 2.9 vs. 2.8, P = 0.04 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Marrs, Meldrum, Muasher, et al., 2004 #13850 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | rFSH+rLH | 90 | 122 | 212 | Comments: Higher # of embryos transferred in Grp 1: 2.9 vs. 2.8, P = 0.04 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Marrs, Meldrum, Muasher, et al., 2004 #13850 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | rFSH | 91 | 128 | 219 | Comments: Higher # of embryos transferred in Grp 1: 2.9 vs. 2.8, P = 0.04 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Marrs, Meldrum, Muasher, et al., 2004 #13850 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | Total | 181 | 250 | 431 | Comments: Higher # of embryos transferred in Grp 1: 2.9 vs. 2.8, P = 0.04 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Marrs, Meldrum, Muasher, et al., 2004 #13850 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Higher # of embryos transferred in Grp 1: 2.9 vs. 2.8, P = 0.04 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Marrs, Meldrum, Muasher, et al., 2004 #13850 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.02 | 0.82 | 1.28 | Comments: Higher # of embryos transferred in Grp 1: 2.9 vs. 2.8, P = 0.04 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Marrs, Meldrum, Muasher, et al., 2004 #13850 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | 2) Subgroup—women 35 or older | | | | Comments: Higher # of embryos transferred in Grp 1: 2.9 vs. 2.8, P = 0.04 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Marrs, Meldrum, Muasher, et al., 2004 #13850 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: Higher # of embryos transferred in Grp 1: 2.9 vs. 2.8, P = 0.04 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Marrs, Meldrum, Muasher, et al., 2004 #13850 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | Study group | 27 | 38 | 65 | Comments: Higher # of embryos transferred in Grp 1: 2.9 vs. 2.8, P = 0.04 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Marrs, Meldrum, Muasher, et al., 2004 #13850 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | Control | 17 | 39 | 56 | Comments: Higher # of embryos transferred in Grp 1: 2.9 vs. 2.8, P = 0.04 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Marrs, Meldrum, Muasher, et al., 2004 #13850 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | | 44 | 77 | 121 | Comments: Higher # of embryos transferred in Grp 1: 2.9 vs. 2.8, P = 0.04 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Marrs, Meldrum, Muasher, et al., 2004 #13850 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Higher # of embryos transferred in Grp 1: 2.9 vs. 2.8, P = 0.04 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Rel risk | 1.37 | 0.84 | 2.23
Martinez, Coroleu, Parera, et al., 2000 #58390 | Geographical location: Barcelona, Spain Study dates: Jan 1996–Sep 1996 Size of population (no. of patients): 310 Number of cycles analyzed: 310 Number of cycles per patient: 1.0 Study type: RCT Interventions: GnRH agonist, hMG COH, randomized to; (a) 10 mg vaginal micronized progesterone daily for 10 days after transfer, or; (b) 2500 IU hCG days 2, 4, 6 | Age: Mean (SD): hCG: 32.9 (3.5) Progesterone: 32.9 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - BMI 22–25; - FSH < 12; - Normal response to COH; - Embryos for transfer; Exclusion criteria: History of OHSS | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28 days after transfer Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Martinez, Coroleu, Parera, et al., 2000 #58390 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28 days after transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Martinez, Coroleu, Parera, et al., 2000 #58390 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28 days after transfer Live birth: NR Multiples: NR Complications: NR | hCG | 47 | 95 | 142 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Martinez, Coroleu, Parera, et al., 2000 #58390 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28 days after transfer Live birth: NR Multiples: NR Complications: NR | Prog | 65 | 103 | 168 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Martinez, Coroleu, Parera, et al., 2000 #58390 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28 days after transfer Live birth: NR Multiples: NR Complications: NR | Total | 112 | 198 | 310 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Martinez, Coroleu, Parera, et al., 2000 #58390 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28 days after transfer Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Rel risk | 0.86 | 0.63 | 1.16
Martinez, Coroleu, Parriego, et al., 2001 #5330 | Geographical location: Barcelona, Spain Study dates: Jun – Oct 1999 Size of population: Grp 1: 51 Grp 2: 49 Number of cycles analyzed: 100 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: Immediate withdraw of catheter after embryo transfer Grp 2: 30 sec delayed removal of catheter after embryo transfer IVF/ICSI with long GnRH downregulation, FSH stimulation and transfer of 2–3 embryos on days 2–3 or 5–6 | Age: Grp 1 Mean (SD): 34.33 (4.27) Grp 2 Mean (SD): 34.52 (3.92) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1 Unexplained infertility: 7 [14] Endometriosis: 4 [8] Male factor: 9 [18] Tubal factor: 22 [44] Other (not specified): 8 [16] Grp 2 Unexplained infertility: 6 [12.2] Endometriosis: 4 [8.2] Male factor: 9 [18.4] Tubal factor: 19 [38.8] Other (not specified): 10 [22.4] Inclusion criteria:; - IVF/ICSI pt with at least 2 embryos of “good quality”; - No difficulty with trial transfer; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: sac only Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy rate: | | | | Comments:; - Low power; - No power analysis; Quality assessment: Randomization method: + (randomized sequentially) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Martinez, Coroleu, Parriego, et al., 2001 #5330 | | | Definition(s) of outcome(s): Pregnancy: sac only Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments:; - Low power; - No power analysis; Quality assessment: Randomization method: + (randomized sequentially) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Martinez, Coroleu, Parriego, et al., 2001 #5330 | | | Definition(s) of outcome(s): Pregnancy: sac only Live birth: NR Multiples: NR Complications: NR | Immed withdrawal | 31 | 20 | 51 | Comments:; - Low power; - No power analysis; Quality assessment: Randomization method: + (randomized sequentially) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Martinez, Coroleu, Parriego, et al., 2001 #5330 | | | Definition(s) of outcome(s): Pregnancy: sac only Live birth: NR Multiples: NR Complications: NR | 30 s delay | 34 | 15 | 49 | Comments:; - Low power; - No power analysis; Quality assessment: Randomization method: + (randomized sequentially) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Martinez, Coroleu, Parriego, et al., 2001 #5330 | | | Definition(s) of outcome(s): Pregnancy: sac only Live birth: NR Multiples: NR Complications: NR | Total | 65 | 35 | 100 | Comments:; - Low power; - No power analysis; Quality assessment: Randomization method: + (randomized sequentially) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Martinez, Coroleu, Parriego, et al., 2001 #5330 | | | Definition(s) of outcome(s): Pregnancy: sac only Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments:; - Low power; - No power analysis; Quality assessment: Randomization method: + (randomized sequentially) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.88 | 0.66 | 1.17
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | Geographical location: Amsterdam and Groeningen, the Netherlands Study dates: May 2003–Jan 2007 Size of population (no. of patients): 408 Number of cycles analyzed: 836 Number of cycles per patient: 2.0 Study type: RCT Interventions: Pre-implantation genetic diagnosis with transfer of only chromosomally normal embryos (n = 2), vs. no PGD (n = 2) Treatment allocated for duration of therapy (up to 3 cycles) | Age: Mean (SD): PGD: 38.0 (1.7) Control: 37.9 (1.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 151 (37%) Endometriosis: 19 (4%) Male factor: 156 (38%) Tubal factor: 92 (23%) PCOS: 25 (6%) Other: Cervical: 17 (4%) Ovarian failure (donor eggs): 3 (<1%) Inclusion criteria:; - Age 35–41; - Eligible for IVF; - No previous failed IVF cycles; - Did not object to a possible double embryo transfer; Exclusion criteria: Exclusion criteria for IVF (not described in detail) | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | | Preg + | Preg = | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | PGD | 61 | 145 | 206 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | No PGD | 88 | 114 | 202 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | | 149 | 259 | 408 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | Rel risk | 0.68 | 0.52 | 0.88 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | 2) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | | Preg + | Preg = | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | PGD | 52 | 154 | 206 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | No PGD | 74 | 128 | 202 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | | 126 | 282 | 408 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | Rel risk | 0.69 | 0.51 | 0.93 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | 3) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | | Preg + | Preg = | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | PGD | 49 | 157 | 206 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | No PGD | 71 | 131 | 202 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | | 120 | 288 | 408 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Mastenbroek, Twisk, van Echten-Arends, et al., 2007 #73010 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac at 7 weeks Ongoing pregnancy (primary outcome): Live birth: Yes Multiples: NR Complications: Trisomy, early pregnancy loss | Rel risk | 0.68 | 0.50 | 0.92 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
4) 1 trisomy 18 in both groups, 3 ante- or post-partum losses in both groups
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | Geographical location: Baracaldo, Spain Study dates: NR Size of population (no. of patients): 515 Number of cycles analyzed: 515 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - Mock transfer during cycle prior to study cycle; - Frydman catheter; - Embryo transfer 2–3 days after retrieval (86%); - U/S: transabdominal U/S guidance; embryos released when catheter tip within 1 cm of fundus; - Clinical touch: when clinician judgment of tip within 1 cm, based on mock transfer results | Age (mean [SD]): U/S: 34.0 (3.1) Clinical touch: 34.2 (3.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 102 (19.9%) Endometriosis: 35 (6.8%) Male factor: 147 (28.7) Tubal factor: 159 (31.0%) Failed IUI: 86 (16.8) Inclusion criteria: Age < 40, scheduled for IVF (ICSI not done at time of study) Exclusion criteria: Cryopreserved embryos, embryos from donated oocytes | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | U/S | 67 | 188 | 255 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Control | 47 | 213 | 260 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 114 | 401 | 515 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.45 | 1.04 | 2.02 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | U/S | 57 | 198 | 255 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Control | 37 | 223 | 260 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 94 | 421 | 515 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.57 | 1.08 | 2.29 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 3) Multiple pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Study drug | 22 | 45 | 67 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Control | 14 | 33 | 47 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 36 | 78 | 114 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Matorras, Urquijo, Mendoza, et al., 2002 #1660 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.10 | 0.63 | 1.92 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
4) Proportion of transfers judged “easy” significantly higher in U/S group (96.9% vs 80.8% in controls).
McIlveen, Lok, Pritchard, et al., 2005 #39890 | Geographical location: Sheffield, UK Study dates: 9/2002 – 5/2004 Size of population: Grp 1: Wallace-75 Grp 2: Cook-75 (cycles—142 subjects) Number of cycles analyzed: 150 Number of cycles per patient: 1.06 Study type: RCT Interventions: Women undergoing IVF/ICSI randomized to embryo transfer with either the Wallace or Cook K-Jet catheter | Age: Grp 1: Mean (SD): 32.7 Range: 21–39 Grp 2: Mean (SD): 32.3 Range: 21–39 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: NR Endometriosis: NR Male factor: NR Tubal factor: NR PCOS: NR Inclusion criteria: NR Exclusion criteria: Age < 39, high basal FSH, previous difficult ET, > 6 previous ETs | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | 1) Pg rate Grp 1 vs 2: | | | | Comments: 8 women received more than 1 cycle—unclear if same instrument was used in both cycles Quality assessment: Randomization method: + Blinding: pt yes, investigator-no Dropout rate < 20%: + Adequacy of randomization concealment: +
McIlveen, Lok, Pritchard, et al., 2005 #39890 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | | pg pos | pg neg | Total
McIlveen, Lok, Pritchard, et al., 2005 #39890 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | Wallace | 22 | 53 | 75
McIlveen, Lok, Pritchard, et al., 2005 #39890 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | Cook | 23 | 52 | 75
McIlveen, Lok, Pritchard, et al., 2005 #39890 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | Total | 45 | 105 | 150
McIlveen, Lok, Pritchard, et al., 2005 #39890 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.96 | 0.59 | 1.56
Mikkelsen, Smith, and Lindenberg, 2000 #6160 | Geographical location: Copenhagen, Denmark Study dates: NR Size of population: Grp1: 10 Grp 2: 10 Number of cycles analyzed: 20 Number of cycles per patient: 1.00 Study type: RCT Interventions: ICSI cycle of in vitro maturation of immature oocytes Grp 1: no stimulation Grp 2: 150 IU rFSH for cycle days 3–5 | Age: Range: 18–37 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Male factor or tubal infertility; - Normo-ovulatory; Exclusion criteria:; - “Endocrine abnormality,” e.g., hyperprolactinemia; - Day 3 antral follicle ct < 3; - Day 3 FSH > 15 and/or inhibin B < 45; - More than 3 previous failed IVF attempts; - < 20% embryo cleavage rate on previous IVF; - Women with PCOS | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy rate: | | | | Comments:; - Low power; - 2 other separate studies reported in the paper could not be evaluated due to pts having multiple cycles and pg rate not given per pt; Quality assessment: Randomization method: - (method NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Mikkelsen, Smith, and Lindenberg, 2000 #6160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total
Mikkelsen, Smith, and Lindenberg, 2000 #6160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Grp 1 | 3 | 7 | 10
Mikkelsen, Smith, and Lindenberg, 2000 #6160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Grp 2 | 2 | 8 | 10
Mikkelsen, Smith, and Lindenberg, 2000 #6160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 5 | 15 | 20
Mikkelsen, Smith, and Lindenberg, 2000 #6160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.50 | 0.32 | 7.14
Mochtar and Dutch Banirelix Study Group, 2004 #11570 | Geographical location: Amsterdam, Netherlands Study dates: 4/2001 – 10/2002 Size of population: Grp 1: 101 Grp 2: 103 Number of cycles analyzed: 204 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: GnRH antagonist started when lead follicle 15 mm. Grp 2: GnRH antagonist started on stimulation day 6 All received IVF/ICSI with rFSH | Age: Grp 1: Mean (SD): 33.1 (3.6) Median: NR Range: NR Grp 2: Mean (SD): 33.0 (3.4) Median: NR Range: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1: Unexplained infertility:28 [27.7] Endometriosis: 3 [3] Male factor: 42 [41.6] Tubal factor:18 [17.8] PCOS: 0 Cervical factor: 3 [3] Other (specify): 3 [3] Grp 2 Unexplained infertility:29 [28.2] Endometriosis: 4 [3.9] Male factor: 40 [39.8] Tubal factor:18 [17.5] PCOS: 0 Cervical factor: 0 Other (specify): 5 [5] Inclusion criteria: Age 18–39, BMI 18–29, regular cycle of 24d–35d with individual variation of 3d Exclusion criteria: Contraindication to GnRH antagonist, PCOS, ovarian cyst, hx oophorectomy, > 3 previous IVF attempts, hx of previous low response | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: +FCM at 8 wks EGA Live birth: NR Multiples: NR Complications: NR | 1) Clinical preg rate: | | | | Comments: Preg not primary outcome of study (powered for difference of total number of retrieved oocytes of 2) Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mochtar and Dutch Banirelix Study Group, 2004 #11570 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: +FCM at 8 wks EGA Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Mochtar and Dutch Banirelix Study Group, 2004 #11570 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: +FCM at 8 wks EGA Live birth: NR Multiples: NR Complications: NR | Day 6 | 34 | 69 | 103
Mochtar and Dutch Banirelix Study Group, 2004 #11570 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: +FCM at 8 wks EGA Live birth: NR Multiples: NR Complications: NR | Follicle size | 23 | 78 | 101
Mochtar and Dutch Banirelix Study Group, 2004 #11570 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: +FCM at 8 wks EGA Live birth: NR Multiples: NR Complications: NR | | 57 | 147 | 204
Mochtar and Dutch Banirelix Study Group, 2004 #11570 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: +FCM at 8 wks EGA Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Mochtar and Dutch Banirelix Study Group, 2004 #11570 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: +FCM at 8 wks EGA Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.45 | 0.92 | 2.28
Mochtar and Dutch Banirelix Study Group, 2004 #11570 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: +FCM at 8 wks EGA Live birth: NR Multiples: NR Complications: NR | 2) Ongoing preg rate:
Mochtar and Dutch Banirelix Study Group, 2004 #11570 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: +FCM at 8 wks EGA Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Mochtar and Dutch Banirelix Study Group, 2004 #11570 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: +FCM at 8 wks EGA Live birth: NR Multiples: NR Complications: NR | Study drug | 32 | 71 | 103
Mochtar and Dutch Banirelix Study Group, 2004 #11570 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: +FCM at 8 wks EGA Live birth: NR Multiples: NR Complications: NR | Control | 22 | 79 | 101
Mochtar and Dutch Banirelix Study Group, 2004 #11570 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: +FCM at 8 wks EGA Live birth: NR Multiples: NR Complications: NR | | 54 | 150 | 204
Mochtar and Dutch Banirelix Study Group, 2004 #11570 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: +FCM at 8 wks EGA Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 1.43 | 0.89 | 2.28
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | Geographical location: Amsterdam, the Netherlands Study dates: Jan 1993–Dec 1997 Size of population (no. of patients): 385 randomized; 355 treated Number of cycles analyzed: 355 Number of cycles per patient: 1.0 Study type: RCT Interventions: GnRH agonist long protocol COH; randomized to 400 mg vaginal progesterone daily, starting; (a) at hCG administration for ovulation (hCG); (b) evening after oocyte retrieval (OR); (c) evening after embryo transfer (ET) | Age: Mean (SD): HCG: 34.4 (3.9) OR: 33.7 (4.5) ET 33.6 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 30% Male factor: 29% Tubal factor: 31% Other: 10% Inclusion criteria: 1^st^ IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | 1) Clinical pregnancy, day of embryo transfer vs day of hCG: | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | hCG | 33 | 97 | 130 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | ET | 41 | 86 | 127 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | | 74 | 183 | 257 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.79 | 0.53 | 1.16 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | 2) Clinical pregnancy, day of embryo transfer vs day of hCG: | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | OR | 39 | 88 | 127 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | ET | 41 | 86 | 127 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | | 80 | 174 | 254 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.95 | 0.66 | 1.37 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Mochtar, Van Wely, and Van der Veen, 2006 #54210 | | | Definition(s) of outcome(s): Pregnancy: Clinical: gestational sac on U/S 35^th^ day after retrieval Ongoing pregnancy: + FHR after 10 weeks Live birth: Yes Multiples: NR Complications: NR | 3) OR vs hCG: 1.21 (0.82, 1.79) | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
4) Live birth, hCG vs ET: 0.98 (0.6, 1.59); OR vs ET: 1.03 (0.64, 1.66); OR vs hCG: 1.05 (0.65, 1.7)
Mohamed, Sbracia, Pacchiarotti, et al., 2006 #54220 | Geographical location: Rome, Italy Study dates: NR Size of population (no. of patients): 257 (analysis done for 241) Number of cycles analyzed: 257 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - Long protocol GnRH agonist (buserelin) downregulation; - Randomized to; (a) 300 IU rFSH or; (b) 300 IU/day uFSH; Gonadotropins started day 2 of menses, continued at fixed dose for 7 days.; - Dose adjusted based on ovarian response (u/s and E2); - Ovulation triggered when E2 1,000–4,500 pg/mL + at least 4 follicles > 16 mm mean diameter | Age: Mean (SD): rFSH 40.9 (1.6); uFSH 41.3 (1.3) Range: 39–43 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 16% Endometriosis: 17% Inclusion criteria:; - Age > 39; - Scheduled for IVF; - Day 3 FSH < 10, E2<60; Exclusion criteria:; - PCOS | Definition(s) of outcome(s): Pregnancy: Gestational sac 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: Primary outcome amount of FSH used Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mohamed, Sbracia, Pacchiarotti, et al., 2006 #54220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: Primary outcome amount of FSH used Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mohamed, Sbracia, Pacchiarotti, et al., 2006 #54220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | uFSH | 23 | 106 | 129 | Comments: Primary outcome amount of FSH used Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mohamed, Sbracia, Pacchiarotti, et al., 2006 #54220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | rFSH | 21 | 107 | 128 | Comments: Primary outcome amount of FSH used Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mohamed, Sbracia, Pacchiarotti, et al., 2006 #54220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | 44 | 213 | 257 | Comments: Primary outcome amount of FSH used Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mohamed, Sbracia, Pacchiarotti, et al., 2006 #54220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Primary outcome amount of FSH used Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Mohamed, Sbracia, Pacchiarotti, et al., 2006 #54220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.09 | 0.63 | 1.86 | Comments: Primary outcome amount of FSH used Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
2) Lower cumulative dose for uFSH
Montag, van der Ven, Dorn, et al., 2006 #54250 | Geographical location: Bonn, Germany Study dates: Jan 2001–March 2001 Size of population (no. of patients): 273 Number of cycles analyzed: 273 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to transfer on; (a) Day 3,; (b) Day 4,; (c) Day 5; Only 3 embryos cultured | Age: Median: 34.5; no differences between groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40 years; - Oocyte retrieval for IVF/ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy, Day 4 vs Day 3 (intention-to-treat): | | | | Comments: Randomization based on week, not subject Quality assessment: Randomization method: - Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Montag, van der Ven, Dorn, et al., 2006 #54250 | | Age: Median: 34.5; no differences between groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40 years; - Oocyte retrieval for IVF/ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: Randomization based on week, not subject Quality assessment: Randomization method: - Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Montag, van der Ven, Dorn, et al., 2006 #54250 | | Age: Median: 34.5; no differences between groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40 years; - Oocyte retrieval for IVF/ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Day 4 | 21 | 74 | 95 | Comments: Randomization based on week, not subject Quality assessment: Randomization method: - Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Montag, van der Ven, Dorn, et al., 2006 #54250 | | Age: Median: 34.5; no differences between groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40 years; - Oocyte retrieval for IVF/ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Day 3 | 33 | 57 | 90 | Comments: Randomization based on week, not subject Quality assessment: Randomization method: - Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Montag, van der Ven, Dorn, et al., 2006 #54250 | | Age: Median: 34.5; no differences between groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40 years; - Oocyte retrieval for IVF/ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 54 | 131 | 185 | Comments: Randomization based on week, not subject Quality assessment: Randomization method: - Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Montag, van der Ven, Dorn, et al., 2006 #54250 | | Age: Median: 34.5; no differences between groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40 years; - Oocyte retrieval for IVF/ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Randomization based on week, not subject Quality assessment: Randomization method: - Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Montag, van der Ven, Dorn, et al., 2006 #54250 | | Age: Median: 34.5; no differences between groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40 years; - Oocyte retrieval for IVF/ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.60 | 0.38 | 0.96 | Comments: Randomization based on week, not subject Quality assessment: Randomization method: - Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Montag, van der Ven, Dorn, et al., 2006 #54250 | | Age: Median: 34.5; no differences between groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40 years; - Oocyte retrieval for IVF/ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 2) Clinical pregnancy, Day 5 vs Day 3: | | | | Comments: Randomization based on week, not subject Quality assessment: Randomization method: - Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Montag, van der Ven, Dorn, et al., 2006 #54250 | | Age: Median: 34.5; no differences between groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40 years; - Oocyte retrieval for IVF/ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: Randomization based on week, not subject Quality assessment: Randomization method: - Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Montag, van der Ven, Dorn, et al., 2006 #54250 | | Age: Median: 34.5; no differences between groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40 years; - Oocyte retrieval for IVF/ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Day 5 | 13 | 75 | 88 | Comments: Randomization based on week, not subject Quality assessment: Randomization method: - Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Montag, van der Ven, Dorn, et al., 2006 #54250 | | Age: Median: 34.5; no differences between groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40 years; - Oocyte retrieval for IVF/ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Day 3 | 33 | 57 | 90 | Comments: Randomization based on week, not subject Quality assessment: Randomization method: - Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Montag, van der Ven, Dorn, et al., 2006 #54250 | | Age: Median: 34.5; no differences between groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40 years; - Oocyte retrieval for IVF/ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 46 | 132 | 178 | Comments: Randomization based on week, not subject Quality assessment: Randomization method: - Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Montag, van der Ven, Dorn, et al., 2006 #54250 | | Age: Median: 34.5; no differences between groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Age < 40 years; - Oocyte retrieval for IVF/ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Randomization based on week, not subject Quality assessment: Randomization method: - Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Rel risk | 0.40 | 0.23 | 0.71
Moon, Choi, Ku, et al., 2007 #71990 | Geographical location: Seoul, South Korea Study dates: Nov 2004–Aug 2005 Size of population (no. of patients): 97 Number of cycles analyzed: 97 Number of cycles per patient: 1.0 Study type: RCT Interventions: GnRH antagonist (Cetrorelix) COH, randomized to new recombinant FSH (DA-3801) vs. follitropin-α | Age: Mean (SD): DA-3801: 31.4 (3.2) Follitropin: 30.8 (2.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Endometriosis: 8 (8.1%) Male factor: 20 (20.6%) Tubal factor: 24 (24.7%) “Other/unknown”: 34 (35.0%) Mixed: 11 (11.3%) Inclusion criteria:; - Age 20–38 years; - BMI 17–29; - Regular menses; - No more than 2 previous attempts; - No clomiphene or gonadotropins within 1 month of consent; Exclusion criteria:; - Systemic disease Cardiovascular/hepatic/renal disease; - Abnormal endocrine test; - PCOS; - Severe endometriosis; - History of poor response in previous IVF/ICSI | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Adequacy of randomization concealment: -
Moon, Choi, Ku, et al., 2007 #71990 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Adequacy of randomization concealment: -
Moon, Choi, Ku, et al., 2007 #71990 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | DA-3801 | 9 | 40 | 49 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Adequacy of randomization concealment: -
Moon, Choi, Ku, et al., 2007 #71990 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Follitropin | 12 | 36 | 48 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Adequacy of randomization concealment: -
Moon, Choi, Ku, et al., 2007 #71990 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Total | 21 | 76 | 97 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Adequacy of randomization concealment: -
Moon, Choi, Ku, et al., 2007 #71990 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Adequacy of randomization concealment: -
Moon, Choi, Ku, et al., 2007 #71990 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.73 | 0.34 | 1.58 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Adequacy of randomization concealment: -
Moon, Choi, Ku, et al., 2007 #71990 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Adequacy of randomization concealment: -
Moon, Choi, Ku, et al., 2007 #71990 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | Live + | Live - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Adequacy of randomization concealment: -
Moon, Choi, Ku, et al., 2007 #71990 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | DA-3801 | 9 | 40 | 49 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Adequacy of randomization concealment: -
Moon, Choi, Ku, et al., 2007 #71990 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Follitropin | 11 | 37 | 48 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Adequacy of randomization concealment: -
Moon, Choi, Ku, et al., 2007 #71990 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Total | 20 | 77 | 97 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Adequacy of randomization concealment: -
Moon, Choi, Ku, et al., 2007 #71990 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Adequacy of randomization concealment: -
Rel risk | 0.80 | 0.37 | 1.76
Moon, Park, Lee, et al., 2004 #12300 | Geographical location: Busan, Korea Study dates: March 1988–Feb 200 Size of population (no. of patients): 188 Number of cycles analyzed: 188 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - All underwent COH with GnRH agonist suppression, hpFSH; - Piroxicam (NSAID): 10 mg 1–2 hours prior to embryo transfer; - Control: placebo 1–2 hours prior to embryo transfer | Age: Mean (SD): Piroxicam 32.7 (4.3), placebo 33.2 (4.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 31 (16.5%) Endometriosis: 17 (9.0%) Male factor: 33 (17.6%) Tubal factor: 107 (56.9%) Inclusion criteria:; - Scheduled for IVF; - Tubal, male, endometriosis, or unexplained infertility; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy, piroxicam vs placebo: | | | | Comments: Randomization apparently stratified by fresh or frozen embryo Quality assessment: Randomization method: - (NR) Blinding: + Dropout rate < 20%: - Adequacy of randomization concealment: - (NR)
Moon, Park, Lee, et al., 2004 #12300 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: Randomization apparently stratified by fresh or frozen embryo Quality assessment: Randomization method: - (NR) Blinding: + Dropout rate < 20%: - Adequacy of randomization concealment: - (NR)
Moon, Park, Lee, et al., 2004 #12300 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Piroxicam | 44 | 50 | 94 | Comments: Randomization apparently stratified by fresh or frozen embryo Quality assessment: Randomization method: - (NR) Blinding: + Dropout rate < 20%: - Adequacy of randomization concealment: - (NR)
Moon, Park, Lee, et al., 2004 #12300 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Placebo | 26 | 68 | 94 | Comments: Randomization apparently stratified by fresh or frozen embryo Quality assessment: Randomization method: - (NR) Blinding: + Dropout rate < 20%: - Adequacy of randomization concealment: - (NR)
Moon, Park, Lee, et al., 2004 #12300 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 70 | 118 | 188 | Comments: Randomization apparently stratified by fresh or frozen embryo Quality assessment: Randomization method: - (NR) Blinding: + Dropout rate < 20%: - Adequacy of randomization concealment: - (NR)
Moon, Park, Lee, et al., 2004 #12300 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Randomization apparently stratified by fresh or frozen embryo Quality assessment: Randomization method: - (NR) Blinding: + Dropout rate < 20%: - Adequacy of randomization concealment: - (NR)
Rel risk | 1.69 | 1.14 | 2.50
Morgia, Sbracia, Schimberni, et al., 2004 #13050 | Geographical location: Rome, Italy Study dates: January 2000–July 2004 Size of population (no. of patients): 129–140 randomized but 11 randomized to natural cycle refused Number of cycles analyzed: 225 Number of cycles per patient: 1.74 Study type: RCT Interventions:; - (a) no stimulation; daily monitoring of E2 and follicles; ovulation triggered by hCG when at least one follicle >16 mm; - (b) 0.05 mg/BID buserelin starting day 1 of cycle and 600 IU purified FSH starting on day 3; - FSH dose adjusted starting day 7; - hCG when 2 follicles > 16 mm | Age: Mean (SD): 39.3 (5.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 24 (18.6%) Male factor: 62 (48.1%) Tubal factor: 19 (14.7%) PCOS: 15 (11.6%) Inclusion criteria:; - Age ≤ 43 years; - Previous IVF cycle with ≤3 follicles recruited or cancelled cycle due to lack of follicle activation; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy (cumulative, per patient): | | | | Comments:; - Continued on allocated treatment for subsequent cycles; - More likely to go to transfer in stimulated group, but higher drop out rate if not pregnant; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Morgia, Sbracia, Schimberni, et al., 2004 #13050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Morgia, Sbracia, Schimberni, et al., 2004 #13050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | uFSH | 7 | 63 | 70
Morgia, Sbracia, Schimberni, et al., 2004 #13050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Natural cycle | 7 | 52 | 59
Morgia, Sbracia, Schimberni, et al., 2004 #13050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 14 | 115 | 129
Morgia, Sbracia, Schimberni, et al., 2004 #13050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Morgia, Sbracia, Schimberni, et al., 2004 #13050 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.84 | 0.31 | 2.27
2) % cycles going to transfer in 1^st^ 2 cycles much higher in stimulated group, similar pregnancy per transfer. Natural cycle group more likely to undergo multiple cycles if not pregnant.
Morgia, Torti, Montigiani, et al., 2006 #54280 | Geographical location: Rome, Italy Study dates: Jan 2002–Dec 2003 Size of population (no. of patients): 709 Number of cycles analyzed: 709 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to; (a) medium buffered only with bicarbonate, vs; (b) medium buffered with N-hydroxyethylpiperazine-N-ethanesulfonate (HEPES), for ICSI, sperm washing, and oocyte retrieval | Age: Mean (SD): HEPES: 35.4 (4.2); bicarbonate 36.1 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Endometriosis: 19% Male factor: 34% Tubal factor: 25% PCOS: 16% Other: 5% Inclusion criteria: 1^st^ ICSI cycle Exclusion criteria: Azoospermia | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Morgia, Torti, Montigiani, et al., 2006 #54280 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Morgia, Torti, Montigiani, et al., 2006 #54280 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | No HEPES | 135 | 222 | 357 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Morgia, Torti, Montigiani, et al., 2006 #54280 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | HEPES | 99 | 252 | 351 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Morgia, Torti, Montigiani, et al., 2006 #54280 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 234 | 474 | 708 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Morgia, Torti, Montigiani, et al., 2006 #54280 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 1.34 | 1.08 | 1.66
Nadir Ciray, Bener, Karagenc, et al., 2005 #41210 | Geographical location: Istanbul, Turkey Study dates: NR Size of population (no. of patients): 90 Number of cycles analyzed: 90 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to; (a) control or; (b) laser assisted hatching day 3 | Age: Mean (SD): Control 34.0 (3.7); hatching 33.1 (4.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Endometriosis: 100% Inclusion criteria: < 40; - Stage 3–4 endometriosis based on laparoscopy at least 3 months previously; Exclusion criteria:; - Zona ≥ 15 μm; - No transfer | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nadir Ciray, Bener, Karagenc, et al., 2005 #41210 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nadir Ciray, Bener, Karagenc, et al., 2005 #41210 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Assisted hatching | 17 | 43 | 60 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nadir Ciray, Bener, Karagenc, et al., 2005 #41210 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | Control | 12 | 18 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nadir Ciray, Bener, Karagenc, et al., 2005 #41210 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | 29 | 61 | 90 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nadir Ciray, Bener, Karagenc, et al., 2005 #41210 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.71 | 0.39 | 1.28
Nagy, Taylor, Elliott, et al., 2005 #39370 | Geographical location: Atlanta, GA Study dates: 7/04 – 1/05 Size of population: Grp 1: 44 no LCR Grp 2: 44 LCR Number of cycles analyzed: 88 Number of cycles per patient: 1.00 Study type: RCT Interventions: LCR = lysed cell removal Women with frozen embryos were randomized to 2 grps. The no LCR grp had embryos replaced as usual. The LCR group had assisted hatching with removal of fragmented blastomeres. | Age: Grp 1: Mean (SD): 35.6 [4.89] Grp 2: Mean (SD): 35.8 [5.12] Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women with embryos previously frozen on day 3 after an IVF cycle Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy rate grp 1 vs 2: | | | | Comments:; - No diagnoses, no info as to pregnancy outcome in fresh cycle.; - No control for effect of assisted hatching; Quality assessment: Randomization method: NR Blinding: NR Dropout rate < 20%: + Adequacy of randomization concealment: NR
Nagy, Taylor, Elliott, et al., 2005 #39370 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Nagy, Taylor, Elliott, et al., 2005 #39370 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | LCR + assisted hatching | 24 | 20 | 44
Nagy, Taylor, Elliott, et al., 2005 #39370 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | No LCR | 10 | 34 | 44
Nagy, Taylor, Elliott, et al., 2005 #39370 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | | 34 | 54 | 88
Nagy, Taylor, Elliott, et al., 2005 #39370 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 2.40 | 1.31 | 4.41
Ng, Chui, Tang, et al., 2001 #58420 | Geographical location: Hong Kong, China Study dates: June 1999–March 2000 Size of population (no. of patients): 150 Number of cycles analyzed: 150 Number of cycles per patient: 1.0 Study type: RCT Interventions: Oocyte retrieval with; (a) paracervical block + placebo, or; (b) paracervical block with conscious sedation | Age: Mean (SD): 35.0 Range: 27–43 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Previous attempt of transvaginal retrieval at study unit; - Presence of follicles in both ovaries; Exclusion criteria:; - First IVF cycle; - General anesthesia requested by patient; - < 3 dominant follicles present; - Presence of dominant follicles in one ovary only; - History of sensitivity to lignocaine | Definition(s) of outcome(s): Main outcome pain measured by visual analog scale Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Chui, Tang, et al., 2001 #58420 | | | Definition(s) of outcome(s): Main outcome pain measured by visual analog scale Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Chui, Tang, et al., 2001 #58420 | | | Definition(s) of outcome(s): Main outcome pain measured by visual analog scale Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | Sedation | 18 | 57 | 75 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Chui, Tang, et al., 2001 #58420 | | | Definition(s) of outcome(s): Main outcome pain measured by visual analog scale Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | Placebo | 19 | 56 | 75 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Chui, Tang, et al., 2001 #58420 | | | Definition(s) of outcome(s): Main outcome pain measured by visual analog scale Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | Total | 37 | 113 | 150 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Chui, Tang, et al., 2001 #58420 | | | Definition(s) of outcome(s): Main outcome pain measured by visual analog scale Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Chui, Tang, et al., 2001 #58420 | | | Definition(s) of outcome(s): Main outcome pain measured by visual analog scale Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | Rel risk | 0.95 | 0.54 | 1.66 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
2) Pain levels during procedure significantly higher without sedation. Overall satisfaction similar.
Ng, Lau, Yeung, et al., 2001 #58430 | Geographical location: Hong Kong, China Study dates: NR Size of population (no. of patients): 40 Number of cycles analyzed: 40 Number of cycles per patient: 1.0 Study type: RCT Interventions: Long protocol GnRH, ICSI for male factor, randomized to COH with; (a) hMG; (b) rFSH | Age: Mean: hMG: 33.0 rFSH: 34.0 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 40 (100%) Inclusion criteria:; - Age < 40; - FSH > 10 on day 2; - Regular cycles; - Severe oligospermia; Exclusion criteria:; - Smokers; - History of ovarian surgery; - Testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28 days post-transfer Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Lau, Yeung, et al., 2001 #58430 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28 days post-transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Lau, Yeung, et al., 2001 #58430 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28 days post-transfer Live birth: NR Multiples: NR Complications: NR | rFSH | 4 | 16 | 20 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Lau, Yeung, et al., 2001 #58430 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28 days post-transfer Live birth: NR Multiples: NR Complications: NR | hMG | 5 | 15 | 20 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Lau, Yeung, et al., 2001 #58430 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28 days post-transfer Live birth: NR Multiples: NR Complications: NR | Total | 9 | 31 | 40 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Lau, Yeung, et al., 2001 #58430 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound 28 days post-transfer Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.80 | 0.25 | 2.55
Ng, Miao, Cheung, et al., 2003 #58440 | Geographical location: Hong Kong, China Study dates: Aug 2000–June 2001 Size of population (no. of patients): 60 Number of cycles analyzed: 60 Number of cycles per patient: 1.0 Study type: RCT Interventions: Cyclogest vaginal suppositories 400 mg twice daily vs. Crinone 8% vaginal gel once daily for 14 days | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Long protocol of pituitary down-regulation used; - Serum oestradiol (E2) level on the day of HCG > 10,000 pmol/l or number of oocytes obtained > 15; Exclusion criteria:; - History of using any vaginal P preparations in previous IVF/ET cycles; - Cancellation of ET because of no oocytes obtained; - Absent fertilization; - E2 on the day of HCG ≥ 30,000 pmol/l | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Miao, Cheung, et al., 2003 #58440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Miao, Cheung, et al., 2003 #58440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Gel | 7 | 23 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Miao, Cheung, et al., 2003 #58440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Suppository | 9 | 21 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Miao, Cheung, et al., 2003 #58440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Total | 16 | 44 | 60 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Miao, Cheung, et al., 2003 #58440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Miao, Cheung, et al., 2003 #58440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.78 | 0.33 | 1.82 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
2) Patient-rated inconvenience, leaking less with gel than suppositories
Ng, Naveed, Lau, et al., 2005 #9340 | Geographical location: Hong Kong, China Study dates: 5/2003 – 5/2004 Size of population: Grp 1: 80 Grp 2: 80 Number of cycles analyzed: 160 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: Laser zona pellucida (ZP) thinning prior to FET. Grp 2: No ZP thinning Protocols used for FET included normal cycles, clomid induced cycles and HRT cycles | Age: Grp 1: Mean (SD): 34 Range: 25–40 Grp 2: Mean (SD): 34 Range: 26–40 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1: Unexplained infertility:9 [11.2] Endometriosis: 10 [12.5] Male factor: 43 [53.8] Tubal factor: 16 [20] Mixed: 2 [2.5] Grp 2: Unexplained infertility:6 [7.5] Endometriosis: 7 [8.7] Male factor: 43 [53.8] Tubal factor: 20 [25] Mixed: 4 [5] Inclusion criteria: 2 or more frozen embryos Exclusion criteria: > 3 previous IVF cycles | Definition(s) of outcome(s): Pregnancy: gest sac on USD or + POC on D+C Ongoing: +FCM at 10–12 wks EGA Live birth: NR Multiples: Yes Complications: NR | 1) Pregnancy rate: | | | | Comments:; - Preg was not primary outcome and insufficient power; - # of embryos replaced was statistically diff between the 2 grps; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ng, Naveed, Lau, et al., 2005 #9340 | | | Definition(s) of outcome(s): Pregnancy: gest sac on USD or + POC on D+C Ongoing: +FCM at 10–12 wks EGA Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg neg | Total
Ng, Naveed, Lau, et al., 2005 #9340 | | | Definition(s) of outcome(s): Pregnancy: gest sac on USD or + POC on D+C Ongoing: +FCM at 10–12 wks EGA Live birth: NR Multiples: Yes Complications: NR | Laser zona thinning | 10 | 70 | 80
Ng, Naveed, Lau, et al., 2005 #9340 | | | Definition(s) of outcome(s): Pregnancy: gest sac on USD or + POC on D+C Ongoing: +FCM at 10–12 wks EGA Live birth: NR Multiples: Yes Complications: NR | Control | 12 | 68 | 80
Ng, Naveed, Lau, et al., 2005 #9340 | | | Definition(s) of outcome(s): Pregnancy: gest sac on USD or + POC on D+C Ongoing: +FCM at 10–12 wks EGA Live birth: NR Multiples: Yes Complications: NR | Total | 22 | 138 | 160
Ng, Naveed, Lau, et al., 2005 #9340 | | | Definition(s) of outcome(s): Pregnancy: gest sac on USD or + POC on D+C Ongoing: +FCM at 10–12 wks EGA Live birth: NR Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Ng, Naveed, Lau, et al., 2005 #9340 | | | Definition(s) of outcome(s): Pregnancy: gest sac on USD or + POC on D+C Ongoing: +FCM at 10–12 wks EGA Live birth: NR Multiples: Yes Complications: NR | Rel risk | 0.83 | 0.38 | 1.82
Ng, Naveed, Lau, et al., 2005 #9340 | | | Definition(s) of outcome(s): Pregnancy: gest sac on USD or + POC on D+C Ongoing: +FCM at 10–12 wks EGA Live birth: NR Multiples: Yes Complications: NR | 2) Multiple pregnancies:
Ng, Naveed, Lau, et al., 2005 #9340 | | | Definition(s) of outcome(s): Pregnancy: gest sac on USD or + POC on D+C Ongoing: +FCM at 10–12 wks EGA Live birth: NR Multiples: Yes Complications: NR | | Multiple | Singleton | Total
Ng, Naveed, Lau, et al., 2005 #9340 | | | Definition(s) of outcome(s): Pregnancy: gest sac on USD or + POC on D+C Ongoing: +FCM at 10–12 wks EGA Live birth: NR Multiples: Yes Complications: NR | Laser zona thinning | 6 | 4 | 10
Ng, Naveed, Lau, et al., 2005 #9340 | | | Definition(s) of outcome(s): Pregnancy: gest sac on USD or + POC on D+C Ongoing: +FCM at 10–12 wks EGA Live birth: NR Multiples: Yes Complications: NR | Control | 2 | 10 | 12
Ng, Naveed, Lau, et al., 2005 #9340 | | | Definition(s) of outcome(s): Pregnancy: gest sac on USD or + POC on D+C Ongoing: +FCM at 10–12 wks EGA Live birth: NR Multiples: Yes Complications: NR | Total | 8 | 14 | 22
Ng, Naveed, Lau, et al., 2005 #9340 | | | Definition(s) of outcome(s): Pregnancy: gest sac on USD or + POC on D+C Ongoing: +FCM at 10–12 wks EGA Live birth: NR Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 3.60 | 0.92 | 14.06
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | Geographical location: Braedstrup, Denmark Study dates: 3/1999 – 4/2000 Size of population: Grp 1: 150 Grp 2: 153 Number of cycles analyzed: 203 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: Stopped supplemental progesterone at time of + hCG Grp 2: Continued progesterone for 3 wks after + hCG Pts with +hCG from IVF/ICSI using a long GnRH downregulation and rFSH | Age: Grp 1: Mean (SD): 32.1 (4.1) Grp 2 Mean (SD): 32.2 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1 Unexplained infertility:50 [33.3] Endometriosis: 0 Male factor: 50 [33.3] Tubal factor: 52 [34.7] PCOS: 13 [8.7] Grp 2 Unexplained infertility:35 [22.8] Endometriosis: 0 Male factor: 56 [3.7] Tubal factor: 58 [37.9] PCOS: 16 [10.4] Total >100 due to multiple diagnoses reported for some couples Inclusion criteria: Serum or urine hCG > 25 IU 14d after transfer Exclusion criteria: More than slight vaginal bleeding before or at the time of hCG measurement | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | 1) Ongoing preg: | | | | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | | Preg + | Preg - | | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | Study drug | 139 | 14 | 153 | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | Control | 133 | 17 | 150 | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | | 272 | 31 | 303 | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | | | Lower 95% CI | Upper 95 % CI | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | Rel risk | 1.02 | 0.95 | 1.11 | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | 2) Delivery: | | | | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | | Birth + | Birth - | | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | Study drug | 126 | 27 | 153 | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | Control | 118 | 32 | 150 | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | | 244 | 59 | 303 | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | | | Lower 95% CI | Upper 95 % CI | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | Rel risk | 1.05 | 0.94 | 1.17 | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Nyboe Andersen, Popovic-Todorovic, Schmidt, et al., 2002 #2780 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy with +FCM at 7 wks Live birth: Yes Multiples: Yes Complications: SAB | 3) No difference in multiple preg rate | | | | Comments: Powered to detect a 10.7% difference in delivery rate Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
4) No difference in SAB rate
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | Geographical location: France Study dates: NR Size of population: Grp 1: 70 Grp 2: 68 Number of cycles analyzed: 138 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: 5 mg NTG patch applied day before transfer until preg test or onset of period Grp 2: placebo patch All wore patches from morning until bedtime All patients had IVF/ICSI with GnRH long protocol and rFSH stimulation | Age: Grp 1 Mean (SD): 34.2 (2.1) Grp 2: Mean (SD): 34.5 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1 Unexplained infertility: 2 [2.8] Endometriosis: 4 [5.7] Male factor: 45 [64.3] Tubal factor: 16 [22.8] PCOS: 0 Other (specify): 3 [4.3] Grp 2 Unexplained infertility: 5 [7.3] Endometriosis: 2 [2.9] Male factor: 37 [54.4] Tubal factor: 18 [26.5] PCOS: 0 Other (specify): 6 [8.8] Inclusion criteria: Hx of 2 or more implantation failures during fresh IVF despite good embryo quality. At least 2 good quality embryos available for transfer Exclusion criteria: Hypersensitivity to NTG, heart failure, severe anemia, high intracranial or intraocular blood pressure | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | 1) Clinical pregnancy rate: | | | | Comments:; - Looks at birth weight in the 2 grps; - Originally powered for 25% diff in preg rate by patches became unavailable during trial resulting in a power of 53% to detect a 25% diff.; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | | Preg + | Preg - | Total
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | Grp 1 | 16 | 54 | 70
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | Grp 2 | 18 | 50 | 68
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | Total | 34 | 104 | 138
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | | Value | Lower 95% CI | Upper 95% CI
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | Rel risk | 0.86 | 0.48 | 1.55
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | 2) NTG related to first-trimester SAB:
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | | SAB+ | SAB- | Total
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | NTG | 1 | 69 | 70
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | placebo | 1 | 67 | 68
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | Total | 2 | 136 | 138
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | | Value | Lower 95% CI | Upper 95% CI
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | Rel risk | 0.97 | 0.06 | 15.22
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | 3) NTG related to ectopic pregnancy:
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | | ect+ | ect- | Total
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | NTG | 1 | 69 | 70
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | placebo | 1 | 67 | 68
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | Total | 2 | 136 | 138
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | | Value | Lower 95% CI | Upper 95% CI
Ohl, Lefebvre-Maunoury, Wittemer, et al., 2002 #930 | | | Definition(s) of outcome(s): Pregnancy: Clinical +FCM at 6 wks EGA Live birth: Yes Multiples: Yes Complications: SAB | Rel risk | 0.97 | 0.06 | 15.22
4) Also compared weights for singletons and for twins; no difference.
Olivennes, Belaisch-Allart, Emperaire, et al., 2000 #8670 | Geographical location: France Study dates: NR Size of population: Grp 1: 115 Grp 2: 39 Number of cycles analyzed: 154 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: Depot GnRH antagonist on day 7 of HMG stim. If ovulation trigger not done within 4 days, then daily GnRH antagonist given until trigger. Grp 2: Depot GnRH agonist during luteal phase All received IVF/ICSI with HMG stimulation Randomized in a 3:1 ratio | Age: Grp 1: Mean (SD): 31.4 (3.7) Median: NR Range: NR Grp 2: Mean (SD): 31.8 (3.8) Median: NR Range: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: NR Endometriosis: NR Male factor: NR Tubal factor: NR PCOS: NR Inclusion criteria: Age 18–39, cycles of 24–35 d with individual variation of ± 3 d, day 3 FSH < 10, nl uterus, ≤ 3 previous IVF attempts. Exclusion criteria: Women with PCOS or stages 3–4 endometriosis | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: + FCM after 12 wks EGA Live birth: NR Multiples: NR Complications: OHSS | 1) Clinical pregnancy rate: | | | | Comments:; - The response rate of GnRH antagonist therapy was the primary outcome.; - Study was not powered for pregnancy differences; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Grp 1 8.7% Grp 2: 9.3% Adequacy of randomization concealment: -
Olivennes, Belaisch-Allart, Emperaire, et al., 2000 #8670 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: + FCM after 12 wks EGA Live birth: NR Multiples: NR Complications: OHSS | | preg + | preg neg | Total
Olivennes, Belaisch-Allart, Emperaire, et al., 2000 #8670 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: + FCM after 12 wks EGA Live birth: NR Multiples: NR Complications: OHSS | Grp 1 | 26 | 89 | 115
Olivennes, Belaisch-Allart, Emperaire, et al., 2000 #8670 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: + FCM after 12 wks EGA Live birth: NR Multiples: NR Complications: OHSS | Grp 2 | 11 | 28 | 39
Olivennes, Belaisch-Allart, Emperaire, et al., 2000 #8670 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: + FCM after 12 wks EGA Live birth: NR Multiples: NR Complications: OHSS | Total | 37 | 117 | 154
Olivennes, Belaisch-Allart, Emperaire, et al., 2000 #8670 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: + FCM after 12 wks EGA Live birth: NR Multiples: NR Complications: OHSS | | Value | Lower 95% CI | Upper 95% CI
Olivennes, Belaisch-Allart, Emperaire, et al., 2000 #8670 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: + FCM after 12 wks EGA Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 0.80 | 0.44 | 1.47
Olivennes, Belaisch-Allart, Emperaire, et al., 2000 #8670 | | | Definition(s) of outcome(s): Pregnancy: Clinical: +FCM Ongoing: + FCM after 12 wks EGA Live birth: NR Multiples: NR Complications: OHSS | 2) Grp 2 had a greater number of oocytes and embryos but the # of embryos transferred was the same
3) No difference in OHSS rates
Orvieto, Kerner, Krissi, et al., 2002 #350 | Geographical location: Tel Aviv, Israel Study dates: NR Size of population (no. of patients): 52 Number of cycles analyzed: 52 Number of cycles per patient: 1 Study type: RCT Interventions: Leuprolide 3.75 mg depot formulation on day 21–23 of the menstrual cycle. Triptorelin 3.75 mg depot formulation on day 21–23 of the menstrual cycle. | Age: Mean (SD): 28.7 ± 4.08 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Age < 37 years, normal uterine cavity, and no hydrosalpinges Exclusion criteria: Chronic illness or receiving chronic medical treatment or repeated IVF failures (> 3 previous cycles) | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy, visualization of a gestational sac by ultrasound and elevation of serum hCG levels. Live birth: NR Multiples: NR Complications: Various (see right) | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Orvieto, Kerner, Krissi, et al., 2002 #350 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Orvieto, Kerner, Krissi, et al., 2002 #350 | | | | Triptorelin | 5 | 21 | 26 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Orvieto, Kerner, Krissi, et al., 2002 #350 | | | | Leuprolide | 12 | 14 | 26 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Orvieto, Kerner, Krissi, et al., 2002 #350 | | | | | 17 | 35 | 52 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Orvieto, Kerner, Krissi, et al., 2002 #350 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Orvieto, Kerner, Krissi, et al., 2002 #350 | | | | Rel risk | 0.42 | 0.17 | 1.02 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
2) There were no cancellations of cycles due to poor response and no case of spontaneous LH surge in either group. None of the patients developed moderate or severe ovarian hyperstimulation syndrome. There was one case of early missed abortion in the leuprolide group and one case of extrauterine pregnancy in the triprorelin group.
Out, David, Ron-El, et al., 2001 #5100 | Geographical location: Haifa, Zerifin, Afula, Tel-Hashomer, and Petach Tiqva, Israel Study dates: May 1997 and June 1999 Size of population (no. of patients): 180 Number of cycles analyzed: 180 Number of cycles per patient: 1 Study type: RCT Interventions: Fixed dose of 100 or 200 IU of rFSH (follatropin beta, Puregon ® NV Organon, Oss, The Netherlands) | Age: Mean (SD): 27.5 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 180 (100%) Tubal factor: Tubal factor also present in 7 subjects Inclusion criteria: Age ≥ 18 and ≤ 37, male infertility, normal regular cycles with mean length between 24 and 35 days, presence of two ovaries, good physical and mental health, body mass index between 18 and 29 kg/m^2^. Exclusion criteria: Female cause for infertility except mild endometriosis or a mechanical factor, previous IVF or ICSI cycles(s) after which less than 3 oocytes were retrieved, previous IVF or ICSI cycles(s) with hospitalization due to ovarian hyperstimulation syndrome, more than four previous IVF or ICSI cycles, total fertilization failure in a previous IVF or ICSI cycle, LH/FSH ratio at screening ≥ 3, chronic cardiovascular, hepatic, renal, or pulmonary disease, history within 12 mo or current abuse of alcohol or drugs, and administration of nonregistered investigational drugs within 3 mo prior to screening. | Definition(s) of outcome(s): Pregnancy: Vital pregnancy: intrauterine pregnancy with positive heart action. Live birth: NR Multiples: NR Complications: OHSS based on investigator report | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Out, David, Ron-El, et al., 2001 #5100 | | | Definition(s) of outcome(s): Pregnancy: Vital pregnancy: intrauterine pregnancy with positive heart action. Live birth: NR Multiples: NR Complications: OHSS based on investigator report | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Out, David, Ron-El, et al., 2001 #5100 | | | Definition(s) of outcome(s): Pregnancy: Vital pregnancy: intrauterine pregnancy with positive heart action. Live birth: NR Multiples: NR Complications: OHSS based on investigator report | Study drug | 21 | 70 | 91 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Out, David, Ron-El, et al., 2001 #5100 | | | Definition(s) of outcome(s): Pregnancy: Vital pregnancy: intrauterine pregnancy with positive heart action. Live birth: NR Multiples: NR Complications: OHSS based on investigator report | Control | 22 | 67 | 89 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Out, David, Ron-El, et al., 2001 #5100 | | | Definition(s) of outcome(s): Pregnancy: Vital pregnancy: intrauterine pregnancy with positive heart action. Live birth: NR Multiples: NR Complications: OHSS based on investigator report | | 43 | 137 | 180 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Out, David, Ron-El, et al., 2001 #5100 | | | Definition(s) of outcome(s): Pregnancy: Vital pregnancy: intrauterine pregnancy with positive heart action. Live birth: NR Multiples: NR Complications: OHSS based on investigator report | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Out, David, Ron-El, et al., 2001 #5100 | | | Definition(s) of outcome(s): Pregnancy: Vital pregnancy: intrauterine pregnancy with positive heart action. Live birth: NR Multiples: NR Complications: OHSS based on investigator report | Rel risk | 0.93 | 0.55 | 1.57 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Out, David, Ron-El, et al., 2001 #5100 | | | Definition(s) of outcome(s): Pregnancy: Vital pregnancy: intrauterine pregnancy with positive heart action. Live birth: NR Multiples: NR Complications: OHSS based on investigator report | 2) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Out, David, Ron-El, et al., 2001 #5100 | | | Definition(s) of outcome(s): Pregnancy: Vital pregnancy: intrauterine pregnancy with positive heart action. Live birth: NR Multiples: NR Complications: OHSS based on investigator report | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Out, David, Ron-El, et al., 2001 #5100 | | | Definition(s) of outcome(s): Pregnancy: Vital pregnancy: intrauterine pregnancy with positive heart action. Live birth: NR Multiples: NR Complications: OHSS based on investigator report | 100 IU | 17 | 74 | 91 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Out, David, Ron-El, et al., 2001 #5100 | | | Definition(s) of outcome(s): Pregnancy: Vital pregnancy: intrauterine pregnancy with positive heart action. Live birth: NR Multiples: NR Complications: OHSS based on investigator report | 200 IU | 15 | 74 | 89 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Out, David, Ron-El, et al., 2001 #5100 | | | Definition(s) of outcome(s): Pregnancy: Vital pregnancy: intrauterine pregnancy with positive heart action. Live birth: NR Multiples: NR Complications: OHSS based on investigator report | | 32 | 148 | 180 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Out, David, Ron-El, et al., 2001 #5100 | | | Definition(s) of outcome(s): Pregnancy: Vital pregnancy: intrauterine pregnancy with positive heart action. Live birth: NR Multiples: NR Complications: OHSS based on investigator report | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Out, David, Ron-El, et al., 2001 #5100 | | | Definition(s) of outcome(s): Pregnancy: Vital pregnancy: intrauterine pregnancy with positive heart action. Live birth: NR Multiples: NR Complications: OHSS based on investigator report | Rel risk | 1.11 | 0.59 | 2.08 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
3) OHSS requiring hospitalization was reported in four cases, all in the high dose group. One ectopic pregnancy occurred in the high dose group.
Out, Rutherford, Fleming, et al., 2004 #14220 | Geographical location: Bristol, UK Study dates: 6/2000 – 12/2001 Size of population: Grp 1: 131 Grp 2: 126 Number of cycles analyzed: 257 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: 150 IU rFSH Grp 2: 200 IU rFSH All received IVF/ICSI with GnRH antagonist starting on day 6. After day 5 dose could be adjusted down to 100 IU. | Age: Grp 1: Mean (SD): 32.7 (3.6) Grp 2 Mean (SD): 32.2 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1 Unexplained infertility:28 [21.4] Endometriosis: 7 [5.3] Male factor: 43 [32.8] Tubal factor: 40 [30.5] PCOS: 0 Mixed: 13 [10] Grp 2 Unexplained infertility:27 [21.4] Endometriosis: 15 [11.9] Male factor: 49 [38.9] Tubal factor: 28 [22.2] PCOS: 0 Mixed: 7 [5.6] Inclusion criteria: Age 18–39, cycles 24–35 d, BMI 18–29, weight 50–90 kg. Exclusion criteria: PCOS, elevated follicular FSH or LH, ovary or abdominal abnl precluding visualization of at least 1 ovary, only one ovary present, use of hormones within 1 mo, alcohol or drug abuse within 12 mo, other investigational study within 3 mo | Definition(s) of outcome(s): Pregnancy: Vital preg: +FCM Live birth: Yes Multiples: NR Complications: SAB rate | 1) Live birth rate (intent-to-treat): | | | | Comments:; - Study powered to detect a 2.06 difference in # of oocytes recovered.; - Preg not a primary outcome; Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Out, Rutherford, Fleming, et al., 2004 #14220 | | | Definition(s) of outcome(s): Pregnancy: Vital preg: +FCM Live birth: Yes Multiples: NR Complications: SAB rate | | Preg + | Preg -
Out, Rutherford, Fleming, et al., 2004 #14220 | | | Definition(s) of outcome(s): Pregnancy: Vital preg: +FCM Live birth: Yes Multiples: NR Complications: SAB rate | Study drug | 32 | 100 | 132
Out, Rutherford, Fleming, et al., 2004 #14220 | | | Definition(s) of outcome(s): Pregnancy: Vital preg: +FCM Live birth: Yes Multiples: NR Complications: SAB rate | Control | 41 | 91 | 132
Out, Rutherford, Fleming, et al., 2004 #14220 | | | Definition(s) of outcome(s): Pregnancy: Vital preg: +FCM Live birth: Yes Multiples: NR Complications: SAB rate | | 73 | 191 | 264
Out, Rutherford, Fleming, et al., 2004 #14220 | | | Definition(s) of outcome(s): Pregnancy: Vital preg: +FCM Live birth: Yes Multiples: NR Complications: SAB rate | | | Lower 95% CI | Upper 95 % CI
Out, Rutherford, Fleming, et al., 2004 #14220 | | | Definition(s) of outcome(s): Pregnancy: Vital preg: +FCM Live birth: Yes Multiples: NR Complications: SAB rate | Rel risk | 0.78 | 0.53 | 1.16
Out, Rutherford, Fleming, et al., 2004 #14220 | | | Definition(s) of outcome(s): Pregnancy: Vital preg: +FCM Live birth: Yes Multiples: NR Complications: SAB rate | 2) Greater # of oocytes in grp 2 but no difference in good quality embryos
3) No difference in SAB rate
Pabuccu, Onalan, and Kaya, 2007 #72120 | Geographical location: Ankara, Turkey Study dates: Nov 2002–Feb 2006 Size of population (no. of patients): 266 Number of cycles analyzed: 266 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to (a) long protocol GnRH agonist (triptorelin) vs, (b) GnRH antagonist (Cetrorelix) Stratified by endometriosis diagnosis; (a) Stage I–II; (b) resected endometrioma; (c) active endometrioma | Age: Mean (SD): 30.9 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Endometriosis: 100% Inclusion criteria:; - Endometriosis; - Normal uterus/tubes; Exclusion criteria:; - Hydrosalpinx; - Documented tuberculosis; - Male factor infertility; - Thaw cycles | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy, Stage I–II endometriosis: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | GnRH antag | 15 | 35 | 50 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | GnRH agonist | 15 | 33 | 48 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | Total | 30 | 68 | 98 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.96 | 0.53 | 1.74 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | 2) Pregnancy, resected endometrioma: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | GnRH antag | 11 | 29 | 40 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | GnRH agonist | 16 | 25 | 41 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | Total | 27 | 54 | 81 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.70 | 0.37 | 1.33 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | 3) Pregnancy, active endometrioma: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | GnRH antag | 7 | 27 | 34 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | GnRH agonist | 8 | 25 | 33 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | Total | 15 | 52 | 67 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.85 | 0.35 | 2.08 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | 4) Pregnancy, all subjects: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | GnRH antag | 33 | 91 | 124 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | GnRH agonist | 39 | 83 | 122 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | Total | 72 | 174 | 246 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pabuccu, Onalan, and Kaya, 2007 #72120 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.83 | 0.56 | 1.23
Pacchiarotti, Aragona, Gaglione, et al., 2007 #72140 | Geographical location: Rome, Italy Study dates: June 2005–March 2006 Size of population (no. of patients): 119 Number of cycles analyzed: 119 Number of cycles per patient: 1.0 Study type: RCT Interventions: GnRH agonist long-protocol, randomized to; (a) urinary FSH for 6 days, followed by rFSH until hCG administration, or; (b) rFSH from day 2 through hCG | Age: Mean (SD): uFSH/rFSH: 34.1 (2.5) rFSH: 35.1 (3.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 16 (13.4%) Male factor: 47 (39.5%) Tubal factor: 53 (44.5%) Inclusion criteria:; - Infertility attributable to tubal factor, male factor or idiopathic infertility; - Serum hormonal profile (FSH and LH <12 mIU/ml, E2 < 50 pg/ml and prolactin < 30 ng/ml) within the normal range; - Regular ovulatory menstrual cycles; - Presence of normal uterine cavity;; - BMI ≥20–≤26 kg/m^2^; - First IVF treatment; - Age 27–39; Exclusion criteria:; - Previous poor response to gonadotropins; - History of severe OHSS; - Current PCOS; - Male partner had azoospermia; - Clinical signs of infection detected in semen analysis within 12 months before treatment | Definition(s) of outcome(s): Pregnancy: Not defiined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Pacchiarotti, Aragona, Gaglione, et al., 2007 #72140 | | | Definition(s) of outcome(s): Pregnancy: Not defiined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Pacchiarotti, Aragona, Gaglione, et al., 2007 #72140 | | | Definition(s) of outcome(s): Pregnancy: Not defiined Live birth: NR Multiples: NR Complications: NR | uFSH/rFSH | 25 | 33 | 58 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Pacchiarotti, Aragona, Gaglione, et al., 2007 #72140 | | | Definition(s) of outcome(s): Pregnancy: Not defiined Live birth: NR Multiples: NR Complications: NR | rFSH only | 13 | 48 | 61 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Pacchiarotti, Aragona, Gaglione, et al., 2007 #72140 | | | Definition(s) of outcome(s): Pregnancy: Not defiined Live birth: NR Multiples: NR Complications: NR | Total | 38 | 81 | 119 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Pacchiarotti, Aragona, Gaglione, et al., 2007 #72140 | | | Definition(s) of outcome(s): Pregnancy: Not defiined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 2.02 | 1.15 | 3.56
Pakkila, Rasanen, Heinonen, et al., 2005 #41520 | Geographical location: Oulu, Kuopio, and Tampere, Finland Study dates: 2000-2003 Size of population (no. of patients): 374 Number of cycles analyzed: 374 Number of cycles per patient: 1.00 Study type: RCT Interventions:; - COH with long GnRH agonist protocol, 100 mg aspirin or placebo beginning on first day of gonadotropins until menses or negative pregnancy test | Age: Mean (SD): Aspirin 32.0, placebo 31.3 Range: aspirin 24–39, placebo 22–39 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 21% Endometriosis: 20% Male factor: 28% Tubal factor: 14% Other female: 10%, multiple: 6% Inclusion criteria:; - Scheduled for IVF (n=235), ICSI (n=12), or both (n=19); Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | 1) Live birth (intention-to-treat): | | | | Comments:; - Powered to detect 15% difference in pregnancy rate; Quality assessment: Randomization method:+ Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Pakkila, Rasanen, Heinonen, et al., 2005 #41520 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments:; - Powered to detect 15% difference in pregnancy rate; Quality assessment: Randomization method:+ Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Pakkila, Rasanen, Heinonen, et al., 2005 #41520 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | Study drug | 32 | 154 | 186 | Comments:; - Powered to detect 15% difference in pregnancy rate; Quality assessment: Randomization method:+ Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Pakkila, Rasanen, Heinonen, et al., 2005 #41520 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | Control | 37 | 151 | 188 | Comments:; - Powered to detect 15% difference in pregnancy rate; Quality assessment: Randomization method:+ Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Pakkila, Rasanen, Heinonen, et al., 2005 #41520 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | | 69 | 305 | 374 | Comments:; - Powered to detect 15% difference in pregnancy rate; Quality assessment: Randomization method:+ Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Pakkila, Rasanen, Heinonen, et al., 2005 #41520 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments:; - Powered to detect 15% difference in pregnancy rate; Quality assessment: Randomization method:+ Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.87 | 0.57 | 1.34
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | Geographical location: Athens, Greece Study dates: June 2002–Dec 2002 Size of population (no. of patients): 243 Number of cycles analyzed: 243 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to ET on (a) day 2, (b) day 3, or (c) day 6 | Age: Mean (SD): Day 2: 32.4 (6.3), Day 3: 31.3 (5.2), Day 6: 33.1 (5.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - female age ≤40 years,; - ≤ 3previous unsuccessful ART attempts; - IVF or ICSI; - COH with long or short protocol, using GnRH agonist and recombinant FSH.; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | 1) Clinical pregnancy, Day 2 vs Day 3: | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Day 2 | 38 | 43 | 81 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Day 3 | 39 | 42 | 81 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | 77 | 85 | 162 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Rel risk | 0.97 | 0.70 | 1.35 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | 2) Clinical pregnancy, Day 6 vs Day 3: | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Day 6 | 30 | 51 | 81 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Day 3 | 39 | 42 | 81 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | 69 | 93 | 162 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Rel risk | 0.77 | 0.54 | 1.11 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | 3) Ongoing pregnancy, Day 2 vs Day 3: | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Day 2 | 33 | 48 | 81 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Day 3 | 35 | 46 | 81 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | 68 | 94 | 162 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Rel risk | 0.94 | 0.66 | 1.35 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | 4) Ongoing pregnancy, Day 6 vs Day 3: | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Day 6 | 20 | 61 | 81 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Day 3 | 35 | 46 | 81 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | 55 | 107 | 162 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
Pantos, Makrakis, Stavrou, et al., 2004 #13900 | | | Definition(s) of outcome(s): Pregnancy: Pregnancy detected by ultrasound Ongoing pregnancy: beyond 12 weeks Live birth: NR Multiples: Yes Complications: NR | Rel risk | 0.57 | 0.36 | 0.90 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - (not described) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:-
5) Similar numbers of twins, higher-order multiples
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | Geographical location: Brussels, Belgium Study dates: July 2003–Nov 2004 Size of population (no. of patients): 351 Number of cycles analyzed: 351 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to single embryo transfer at (a) day 3 vs (b) day 5; randomization at initial visit, before start of treatment | Age: Mean (SD): Day 3: 30.5 (3.2); Day 5: 30.4 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 31 (8.8%) Male factor: 196 (55.8%) Male + female combined: 21 (6.0%) “Female” factor: 85 (24.2%) Inclusion criteria: < 36 years; - 1^st^ or 2^nd^ ART cycle; - Day 3 FSH ≤ 12 IU/L; Exclusion criteria: PGD | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments:; - Powered to detect 10% absolute difference; - Stopped at interim analysis based on pre-specified stopping rules; Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | Day 5 | 58 | 118 | 176
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | Day 3 | 41 | 134 | 175
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | | 99 | 252 | 351
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.41 | 1.00 | 1.98
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | 2) Ongoing pregnancy:
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | Day 5 | 58 | 118 | 176
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | Day 3 | 38 | 137 | 175
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | | 96 | 255 | 351
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.52 | 1.07 | 2.16
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | 3) Live birth:
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | | Live birth + | Live birth -
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | Day 5 | 56 | 120 | 176
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | Day 3 | 38 | 137 | 175
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | | 94 | 257 | 351
Papanikolaou, Camus, Kolibianakis, et al., 2006 #54790 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: + FHR at 7 weeks Ongoing pregnancy: + FHR after 12 weeks Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 1.47 | 1.03 | 2.09
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | Geographical location: Brussels, Belgium Study dates: 1/01 – 11/03 Size of population: Grp 1: 84 - day 3 Grp 2: 80 - day 5 Number of cycles analyzed: 164 Number of cycles per patient: 1.00 Study type: RCT Interventions: Women with at least 4 good quality embryos on day 3 were randomized to day 3 vs day 5 transfer. Good quality was defined as a min of 6 blastomeres, max of 20% fragmentation, no multinucleated blastomeres. | Age: Grp 1 Mean (SD): 29.6 [0.4] Grp 2: Mean (SD): 29.9 [0.4] Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1: Unexplained infertility: 4 [4.8] Male factor: 46 [55.4] Female factor: 25 [30.1] Combined factors: 8 [9.6] Grp 2: Unexplained infertility: 7 [8.8] Male factor: 43 [53.8] Female factor: 21 [26.3]] Combined factors: 9 [11.3] Inclusion criteria: Age ≤ 37, rank trial ≤ 3, day 3 FSH ≤ 12, use of ejaculated sperm Exclusion criteria: Oocyte donation, PGD | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | 1) Pregnancy rate grp 1 vs 2: | | | | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | Day 5 | 42 | 38 | 80 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | Day 3 | 27 | 57 | 84 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | | 69 | 95 | 164 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 1.63 | 1.12 | 2.37 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | 2) Live birth rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | | Birth + | Birth - | | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | Day 5 | 38 | 42 | 80 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | Day 3 | 23 | 61 | 84 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | | 61 | 103 | 164 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 1.73 | 1.14 | 2.63 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | 3) Multiples: | | | | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | | Mult + | Mult - | | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | Day 5 | 24 | 18 | 42 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | Day 3 | 19 | 8 | 27 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | | 43 | 26 | 69 | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Papanikolaou, D'haeseleer, Verheyen, et al., 2005 #39670 | | | Definition(s) of outcome(s): Pregnancy: +FCM Live birth: Yes Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: no Dropout rate < 20%: + Adequacy of randomization concealment: no
Rel risk | 0.81 | 0.57 | 1.16
Pellicano, Zullo, Florentino, et al., 2001 #3740 | Geographical location: Naples and Catanzaro, Italy Study dates: NR Size of population (no. of patients): 80 Number of cycles analyzed: NR Number of cycles per patient: NR Study type: RCT Interventions: For minilaparoscopic gamete intra-fallopian transfer either: CS: Conscious sedation GA: General anesthesia | Age: Mean (SD): 31 (3.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Infertility duration ≥ 2 years, 3–6 failed IUIC, one patent tube on hysterosalpingography, normal uterine cavity by hysteroscopy, no pelvic pathology on ultrasound, and no metabolic or cardiorespiratory disorders. Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: ultrasound visualization of a gestational sac. Ongoing pregnancy: not defined Live birth: NR Multiples: NR Complications: Ectopic pregnancy, anesthesia complication (not defined) | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pellicano, Zullo, Florentino, et al., 2001 #3740 | | | | | Clin preg + | Clin preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pellicano, Zullo, Florentino, et al., 2001 #3740 | | | | CS | 14 | 26 | 40 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pellicano, Zullo, Florentino, et al., 2001 #3740 | | | | GA | 16 | 24 | 40 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pellicano, Zullo, Florentino, et al., 2001 #3740 | | | | Total | 30 | 50 | 80 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pellicano, Zullo, Florentino, et al., 2001 #3740 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pellicano, Zullo, Florentino, et al., 2001 #3740 | | | | Rel risk | 0.88 | 0.50 | 1.54 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pellicano, Zullo, Florentino, et al., 2001 #3740 | | | | 2) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pellicano, Zullo, Florentino, et al., 2001 #3740 | | | | | Ongoing preg + | Ongoing preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pellicano, Zullo, Florentino, et al., 2001 #3740 | | | | CS | 11 | 29 | 40 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pellicano, Zullo, Florentino, et al., 2001 #3740 | | | | GA | 11 | 29 | 40 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pellicano, Zullo, Florentino, et al., 2001 #3740 | | | | Total | 22 | 58 | 80 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pellicano, Zullo, Florentino, et al., 2001 #3740 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pellicano, Zullo, Florentino, et al., 2001 #3740 | | | | Rel risk | 1.00 | 0.49 | 2.04 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Pellicano, Zullo, Florentino, et al., 2001 #3740 | | | | 3) No difference in operative time, lower discharge time, higher proportion discharged by 2 hr, and lower need for additional anesthesia for CS. | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
4) No difference in ectopic rate (1 in each group) and no anesthesia complications.
Petersen, Mauri, Baruffi, et al., 2002 #290 | Geographical location: SP, Brazil Study dates: NR Size of population: Grp 1: 50 Grp 2: 50 Number of cycles analyzed: 100 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: ZP laser thinning Grp 2: control All received ICSI with GnRH long protocol downregulation and rFSH stimulation for male factor ZP thinned at 4 sites 60–90% | Age: Grp 1 Mean (SD): 39.8 (1.3) Median: NR Range: NR Grp 2 Mean (SD): 40 (1.9) Median: NR Range: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Age ≥ 38, male factor infertility Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: SAB rate | 1) Pregnancy rate: | | | | Comments: No power calculations Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Petersen, Mauri, Baruffi, et al., 2002 #290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: SAB rate | | preg + | preg neg | Total | Comments: No power calculations Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Petersen, Mauri, Baruffi, et al., 2002 #290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: SAB rate | Zona thinning | 8 | 42 | 50 | Comments: No power calculations Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Petersen, Mauri, Baruffi, et al., 2002 #290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: SAB rate | Control | 11 | 39 | 50 | Comments: No power calculations Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Petersen, Mauri, Baruffi, et al., 2002 #290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: SAB rate | Total | 19 | 81 | 100 | Comments: No power calculations Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Petersen, Mauri, Baruffi, et al., 2002 #290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: SAB rate | | Value | Lower 95% CI | Upper 95% CI | Comments: No power calculations Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Petersen, Mauri, Baruffi, et al., 2002 #290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: SAB rate | Rel risk | 0.73 | 0.32 | 1.65 | Comments: No power calculations Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Petersen, Mauri, Baruffi, et al., 2002 #290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: SAB rate | 2) Delivery rate: | | | | Comments: No power calculations Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Petersen, Mauri, Baruffi, et al., 2002 #290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: SAB rate | | preg + | preg neg | Total | Comments: No power calculations Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Petersen, Mauri, Baruffi, et al., 2002 #290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: SAB rate | Zona thinning | 5 | 45 | 50 | Comments: No power calculations Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Petersen, Mauri, Baruffi, et al., 2002 #290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: SAB rate | Control | 5 | 45 | 50 | Comments: No power calculations Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Petersen, Mauri, Baruffi, et al., 2002 #290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: SAB rate | Total | 10 | 90 | 100 | Comments: No power calculations Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Petersen, Mauri, Baruffi, et al., 2002 #290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: SAB rate | | Value | Lower 95% CI | Upper 95% CI | Comments: No power calculations Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Petersen, Mauri, Baruffi, et al., 2002 #290 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: SAB rate | Rel risk | 1.00 | 0.31 | 3.24 | Comments: No power calculations Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
3) No difference in SAB rate
Petersen, Mauri, Baruffi, et al., 2005 #9850 | Geographical location: Sao Paulo, Brazil Study dates: Jan 2002–July 2003 Size of population (no. of patients): 150 Number of cycles analyzed: 150 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to (a) control or (b) ¼ zona laser assisted hatching | Age: Mean (SD): 34.1–35.7 all 4 groups Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 11 (7.3%) Male factor: 61 (40.7%) Other: Female: 47 (31.3%) Mixed: 31 (20.7%) Inclusion criteria:; - ICSI; - history of at least one previous failed ART cycle (randomization stratified by number of previous failures); Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | 1) Clinical pregnancy, 1 previous failure: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Assisted hatching | 11 | 24 | 35 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Control | 10 | 25 | 35 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | 21 | 49 | 70 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.10 | 0.54 | 2.25 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | 2) Live birth, 1 previous failure: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | LB + | LB - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Assisted hatching | 8 | 27 | 35 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Control | 10 | 25 | 35 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | 18 | 52 | 70 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.80 | 0.36 | 1.79 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | 3) Clinical pregnancy, 2 previous failures: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Assisted hatching | 10 | 30 | 40 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Control | 3 | 37 | 40 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | 13 | 67 | 80 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Rel risk | 3.33 | 0.99 | 11.22 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | 4) Live birth, 2 previous failures: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | LB + | LB - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Assisted hatching | 9 | 31 | 40 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Control | 3 | 37 | 40 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | 12 | 68 | 80 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Rel risk | 3.00 | 0.88 | 10.27 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | 5) Clinical pregnancy, all subjects | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Assisted hatching | 21 | 54 | 75 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Control | 13 | 62 | 75 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | 34 | 116 | 150 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.62 | 0.87 | 2.98 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | 6) Live birth, all subjects | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | LB + | LB - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Assisted hatching | 17 | 58 | 75 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | Control | 13 | 62 | 75 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | 30 | 120 | 150 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Petersen, Mauri, Baruffi, et al., 2005 #9850 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR 4 weeks after transfer Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.31 | 0.68 | 2.50
Pinheiro, Cavagna, Baruffi, et al., 2003 #14350 | Geographical location: Ribeirao Preto, Brazil. Study dates: NR Size of population (no. of patients): 225 Number of cycles analyzed: 225 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - All underwent long protocol GnRH, fixed stimuation with rFSH; Group A: 10 mg terbutaline/day for 15 days starting day of oocyte retrieval Group B: 20 mg/day ritrodrine, same schedule Group C: no treatment | Age: Mean (SD): Terbutaline 34.6 (0.5), ritodrine 33.5 (0.7), control: 34.7 (0.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 100% Inclusion criteria:; - Scheduled for ICSI for male factor; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: + hCG; Ultrasound confirmed FHR 14 days after + hCG Live birth: NR Multiples: NR Complications: AEs | 1) Pregnancy, terbutaline vs control (intention to treat): | | | | Comments:; - No adjustment for multiple comparisons; - unclear if reported pregnancy rate is based on hCG or ultrasound results; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: Adequacy of randomization concealment: -
Pinheiro, Cavagna, Baruffi, et al., 2003 #14350 | | | Definition(s) of outcome(s): Pregnancy: + hCG; Ultrasound confirmed FHR 14 days after + hCG Live birth: NR Multiples: NR Complications: AEs | | Preg + | Preg -
Pinheiro, Cavagna, Baruffi, et al., 2003 #14350 | | | Definition(s) of outcome(s): Pregnancy: + hCG; Ultrasound confirmed FHR 14 days after + hCG Live birth: NR Multiples: NR Complications: AEs | Terbutaline | 26 | 64 | 90
Pinheiro, Cavagna, Baruffi, et al., 2003 #14350 | | | Definition(s) of outcome(s): Pregnancy: + hCG; Ultrasound confirmed FHR 14 days after + hCG Live birth: NR Multiples: NR Complications: AEs | Control | 13 | 32 | 45
Pinheiro, Cavagna, Baruffi, et al., 2003 #14350 | | | Definition(s) of outcome(s): Pregnancy: + hCG; Ultrasound confirmed FHR 14 days after + hCG Live birth: NR Multiples: NR Complications: AEs | | 39 | 96 | 135
Pinheiro, Cavagna, Baruffi, et al., 2003 #14350 | | | Definition(s) of outcome(s): Pregnancy: + hCG; Ultrasound confirmed FHR 14 days after + hCG Live birth: NR Multiples: NR Complications: AEs | | | Lower 95% CI | Upper 95 % CI
Pinheiro, Cavagna, Baruffi, et al., 2003 #14350 | | | Definition(s) of outcome(s): Pregnancy: + hCG; Ultrasound confirmed FHR 14 days after + hCG Live birth: NR Multiples: NR Complications: AEs | Rel risk | 1.00 | 0.57 | 1.75
Pinheiro, Cavagna, Baruffi, et al., 2003 #14350 | | | Definition(s) of outcome(s): Pregnancy: + hCG; Ultrasound confirmed FHR 14 days after + hCG Live birth: NR Multiples: NR Complications: AEs | 2) Pregnancy, ritodrine vs control (intention to treat):
Pinheiro, Cavagna, Baruffi, et al., 2003 #14350 | | | Definition(s) of outcome(s): Pregnancy: + hCG; Ultrasound confirmed FHR 14 days after + hCG Live birth: NR Multiples: NR Complications: AEs | | Preg + | Preg -
Pinheiro, Cavagna, Baruffi, et al., 2003 #14350 | | | Definition(s) of outcome(s): Pregnancy: + hCG; Ultrasound confirmed FHR 14 days after + hCG Live birth: NR Multiples: NR Complications: AEs | Ritodrine | 20 | 70 | 90
Pinheiro, Cavagna, Baruffi, et al., 2003 #14350 | | | Definition(s) of outcome(s): Pregnancy: + hCG; Ultrasound confirmed FHR 14 days after + hCG Live birth: NR Multiples: NR Complications: AEs | Control | 13 | 32 | 45
Pinheiro, Cavagna, Baruffi, et al., 2003 #14350 | | | Definition(s) of outcome(s): Pregnancy: + hCG; Ultrasound confirmed FHR 14 days after + hCG Live birth: NR Multiples: NR Complications: AEs | | 33 | 102 | 135
Pinheiro, Cavagna, Baruffi, et al., 2003 #14350 | | | Definition(s) of outcome(s): Pregnancy: + hCG; Ultrasound confirmed FHR 14 days after + hCG Live birth: NR Multiples: NR Complications: AEs | | | Lower 95% CI | Upper 95 % CI
Pinheiro, Cavagna, Baruffi, et al., 2003 #14350 | | | Definition(s) of outcome(s): Pregnancy: + hCG; Ultrasound confirmed FHR 14 days after + hCG Live birth: NR Multiples: NR Complications: AEs | Rel risk | 0.77 | 0.42 | 1.40
3) 30/90 (33%) of ritodrine subjects discontinued because of side effects, 3/90 (3%) of terbutaline subjects
Platteau, Laurent, Albano, et al., 2003 #16630 | Geographical location: Brussels, Belgium Study dates: 9/2000 – 12/2001 Size of population: Grp 1: 96 Grp 2: 104 Number of cycles analyzed: 200 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: Follitropin β with pen device Grp 2 Follitropin α with conventional syringe All underwent IVF/ICSI with long protocol of GnRH agonist followed by 150–225 of Follitropin α or 150–200 of Follitropin β for the first 5d | Age: Grp 1: Mean (SD): 31.3 (4.1) Grp 2 Mean (SD): 31.7 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1 Unexplained infertility: 14 [15] Endometriosis: 0 Male factor: 58 [60] Tubal factor: 15 [16] PCOS: 0 Other (specify): 9 [9] Grp 2 Unexplained infertility: 12 [12] Endometriosis: 0 Male factor: 63 [61] Tubal factor: 20 [19.5] PCOS: 0 Other (specify): 8 [7.5] Inclusion criteria: Age 18–39, ovulatory cycles of 24–35 d, BMI 18–29. Exclusion criteria: Previous IVF in which less than 3 oocytes retrieved, ovarian abnl precluding adequate stimulation, hx hospitalization for severe OHSS, hx of EtOH or drug abuse within 12 mo and previous enrollment in this study. | Definition(s) of outcome(s): Pregnancy: Clinical not defined Live birth: Yes Multiples: NR Complications: NR | 1) Clinical pregnancy rate: | | | | Comments:; - Study powered to detect a 3.6 difference in # of oocytes.; - Preg not a primary outcome; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Platteau, Laurent, Albano, et al., 2003 #16630 | | | Definition(s) of outcome(s): Pregnancy: Clinical not defined Live birth: Yes Multiples: NR Complications: NR | | preg + | preg neg | Total
Platteau, Laurent, Albano, et al., 2003 #16630 | | | Definition(s) of outcome(s): Pregnancy: Clinical not defined Live birth: Yes Multiples: NR Complications: NR | Injector | 34 | 62 | 96
Platteau, Laurent, Albano, et al., 2003 #16630 | | | Definition(s) of outcome(s): Pregnancy: Clinical not defined Live birth: Yes Multiples: NR Complications: NR | Syringe | 36 | 68 | 104
Platteau, Laurent, Albano, et al., 2003 #16630 | | | Definition(s) of outcome(s): Pregnancy: Clinical not defined Live birth: Yes Multiples: NR Complications: NR | Total | 70 | 130 | 200
Platteau, Laurent, Albano, et al., 2003 #16630 | | | Definition(s) of outcome(s): Pregnancy: Clinical not defined Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Platteau, Laurent, Albano, et al., 2003 #16630 | | | Definition(s) of outcome(s): Pregnancy: Clinical not defined Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.02 | 0.70 | 1.49
Platteau, Laurent, Albano, et al., 2003 #16630 | | | Definition(s) of outcome(s): Pregnancy: Clinical not defined Live birth: Yes Multiples: NR Complications: NR | 2) Live birth rate:
Platteau, Laurent, Albano, et al., 2003 #16630 | | | Definition(s) of outcome(s): Pregnancy: Clinical not defined Live birth: Yes Multiples: NR Complications: NR | | preg + | preg neg | Total
Platteau, Laurent, Albano, et al., 2003 #16630 | | | Definition(s) of outcome(s): Pregnancy: Clinical not defined Live birth: Yes Multiples: NR Complications: NR | Injector | 31 | 65 | 96
Platteau, Laurent, Albano, et al., 2003 #16630 | | | Definition(s) of outcome(s): Pregnancy: Clinical not defined Live birth: Yes Multiples: NR Complications: NR | Syringe | 34 | 70 | 104
Platteau, Laurent, Albano, et al., 2003 #16630 | | | Definition(s) of outcome(s): Pregnancy: Clinical not defined Live birth: Yes Multiples: NR Complications: NR | Total | 65 | 135 | 200
Platteau, Laurent, Albano, et al., 2003 #16630 | | | Definition(s) of outcome(s): Pregnancy: Clinical not defined Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.99 | 0.66 | 1.47
Poehl, Holagschwandtner, Bichler, et al., 2001 #4830 | Geographical location: Vienna, Austria Study dates: NR Size of population: Grp 1: 45 Grp 2: 44 Number of cycles analyzed: 89 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: Conventional IVF Grp 2: ICSI All underwent GnRH agonist flare with rFSH stimulation | Age: Grp 1 Mean (SD): 33 (NR) Grp 2: Mean (SD): 32.7 (NR) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Age 18–39, tubo-peritoneal factor infertility, nl uterine cavity, nl day 3 FSH, E, Prl, TSH, nl semen analysis within 6 mo Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy rate: not defined Live birth: NR Multiples: NR Complications: NR | 1) Ongoing pregnancy rate: | | | | Comments: Low power Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Poehl, Holagschwandtner, Bichler, et al., 2001 #4830 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy rate: not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: Low power Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Poehl, Holagschwandtner, Bichler, et al., 2001 #4830 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy rate: not defined Live birth: NR Multiples: NR Complications: NR | Grp 1 | 15 | 30 | 45 | Comments: Low power Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Poehl, Holagschwandtner, Bichler, et al., 2001 #4830 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy rate: not defined Live birth: NR Multiples: NR Complications: NR | Grp 2 | 10 | 34 | 44 | Comments: Low power Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Poehl, Holagschwandtner, Bichler, et al., 2001 #4830 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy rate: not defined Live birth: NR Multiples: NR Complications: NR | Total | 25 | 64 | 89 | Comments: Low power Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Poehl, Holagschwandtner, Bichler, et al., 2001 #4830 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy rate: not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Low power Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 1.47 | 0.74 | 2.91
Popovic-Todorovic, Loft, Bredkjaeer, et al., 2003 #15070 | Geographical location: Copenhagen, Denmark Study dates: 1/2002 – 1/2003 Size of population: Grp 1: 131 Grp 2: 131 Number of cycles analyzed: 262 Number of cycles per patient: 1.00 Study type: RCT Interventions: Grp 1: Individualized rFSH dosing based on normogram Grp 2: Standard FSH dosing IVF/ICSI with GnRH agonist long downregulation. Normogram in grp 1 based on antral follicle ct, ovarian volume, ovarian Doppler score, age, smoking. | Age: Grp 1 Mean (SD): 31.9 (3.9) Grp 2 Mean (SD): 32.7 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1 Unexplained infertility:18 [13.7] Endometriosis: 0 Male factor: 75 [57.3] Tubal factor: 38 [29] PCOS: 0 Other (specify): 4 [3.1] Grp 2 Unexplained infertility:18 [13.7] Endometriosis: 0 Male factor: 79 [60.3] Tubal factor: 36 [27.5] PCOS: 0 Other (specify): 1 [0.8] Inclusion criteria: 1^st^ IVF cycle, basal FSH < 12.5, both ovaries, cycles 21–35, max age 39. Exclusion criteria: Ovarian cysts, inaccessible ovaries | Definition(s) of outcome(s): Pregnancy: Ongoing: not defined Live birth: NR Multiples: NR Complications: NR | 1) Ongoing pregnancy rate: | | | | Comments:; - Sig greater number of embryos transferred in grp 2.; - Sig higher SAB rate in grp 2 contributing to higher ongoing preg rate in grp 1; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Popovic-Todorovic, Loft, Bredkjaeer, et al., 2003 #15070 | | | Definition(s) of outcome(s): Pregnancy: Ongoing: not defined Live birth: NR Multiples: NR Complications: NR | | preg + | preg neg | Total
Popovic-Todorovic, Loft, Bredkjaeer, et al., 2003 #15070 | | | Definition(s) of outcome(s): Pregnancy: Ongoing: not defined Live birth: NR Multiples: NR Complications: NR | Individualized | 48 | 83 | 131
Popovic-Todorovic, Loft, Bredkjaeer, et al., 2003 #15070 | | | Definition(s) of outcome(s): Pregnancy: Ongoing: not defined Live birth: NR Multiples: NR Complications: NR | Standard | 32 | 99 | 131
Popovic-Todorovic, Loft, Bredkjaeer, et al., 2003 #15070 | | | Definition(s) of outcome(s): Pregnancy: Ongoing: not defined Live birth: NR Multiples: NR Complications: NR | Total | 80 | 182 | 262
Popovic-Todorovic, Loft, Bredkjaeer, et al., 2003 #15070 | | | Definition(s) of outcome(s): Pregnancy: Ongoing: not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Popovic-Todorovic, Loft, Bredkjaeer, et al., 2003 #15070 | | | Definition(s) of outcome(s): Pregnancy: Ongoing: not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.50 | 1.03 | 2.18
Popovic-Todorovic, Loft, Bredkjaeer, et al., 2003 #15070 | | | Definition(s) of outcome(s): Pregnancy: Ongoing: not defined Live birth: NR Multiples: NR Complications: NR | 2) SAB rate:
Popovic-Todorovic, Loft, Bredkjaeer, et al., 2003 #15070 | | | Definition(s) of outcome(s): Pregnancy: Ongoing: not defined Live birth: NR Multiples: NR Complications: NR | | SAB yes | SAB no | Total
Popovic-Todorovic, Loft, Bredkjaeer, et al., 2003 #15070 | | | Definition(s) of outcome(s): Pregnancy: Ongoing: not defined Live birth: NR Multiples: NR Complications: NR | Individualized | 0.5 | 48 | 48.5
Popovic-Todorovic, Loft, Bredkjaeer, et al., 2003 #15070 | | | Definition(s) of outcome(s): Pregnancy: Ongoing: not defined Live birth: NR Multiples: NR Complications: NR | Standard | 5 | 27 | 32
Popovic-Todorovic, Loft, Bredkjaeer, et al., 2003 #15070 | | | Definition(s) of outcome(s): Pregnancy: Ongoing: not defined Live birth: NR Multiples: NR Complications: NR | Total | 5.5 | 75 | 80.5
Popovic-Todorovic, Loft, Bredkjaeer, et al., 2003 #15070 | | | Definition(s) of outcome(s): Pregnancy: Ongoing: not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.07 | 0.00 | 1.17
Primi, Senn, Montag, et al., 2004 #11230 | Geographical location: Lausanne, Switzerland; Bonn, Germany; Paris, France; Barcelona, Spain Study dates: NR Size of population (no. of patients): 246 in Groups I and II Number of cycles analyzed: 246 Number of cycles per patient: 1.0 Study type: RCT Interventions: Two sets of patients:; (I) first cycle frozen-thawed embryos; (II) poor prognosis (age > 37 or basal FSH >10 IU/L) undergoing 1^st^ cycle of fresh embryos, randomized to 1 of 3 groups:; (a) no assisted hatching + placebo; (b) assisted hatching + placebo; (c) assisted hatching + methylprednisone + doxycycline 2 days prior through 5 days post transfer | Age: Mean (SD): Group I: 31.7–32.8; Group II: 38.3–40.1 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 28 (11.4%) Male factor: 117 (49.4%) Other: Female: 78 (32.9%) Mixed: 16 (6.8%) Inclusion criteria:; (i) 20 –45 years old,; (ii) having at least one functional ovary,; (iii) having normal FSH (between 3 and 12 IU/l) and prolactin (<30 mg/l); (iv) having no clinically significant abnormal findings within 6 months before treatment start,; (v) no pelvic inflammatory disease between the previous assessment and study entry,; (vi) having a normal uterine cavity as documented within; 5 years prior to treatment assignment by a hysteroscopy, hysterosalpingography or hysterosonography, Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | 1) Group I (frozen-thawed), control vs assisted hatching + placebo: | | | | Comments: - In group 2, mean age of hatching + active drug (40.1) higher than placebo (38.3)—although not statistically significant, may be clinically relevant Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | Hatching + placebo | 1 | 61 | 62
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | Control | 8 | 45 | 53
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | | 9 | 106 | 115
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.11 | 0.01 | 0.83
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | 2) Group I (frozen-thawed), control vs assisted hatching + methylprednisolone + doxycycline:
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | Hatching + drugs | 6 | 50 | 56
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | Control | 8 | 45 | 53
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | | 14 | 95 | 109
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.71 | 0.26 | 1.91
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | 3) Group II (poor prognosis, fresh embryo), control vs assisted hatching + placebo:
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | Study drug | 3 | 19 | 22
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | Control | 5 | 16 | 21
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | | 8 | 35 | 43
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.57 | 0.16 | 2.10
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | 4) Group II (poor prognosis, fresh embryo), control vs assisted hatching + methylprednisolone + doxycycline:
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | Study drug | 5 | 18 | 23
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | Control | 5 | 16 | 21
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | | 10 | 34 | 44
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Primi, Senn, Montag, et al., 2004 #11230 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.91 | 0.31 | 2.71
5) Patterns similar for live birth; sample size too small to draw conclusions
Propst, Bates, Robinson, et al., 2006 #55060 | Geographical location: San Antonio, TX Study dates: NR Size of population (no. of patients): 60 Number of cycles analyzed: 60 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - OCPs on cycle prior to COH; - rFSH 150–300 IU/day on day 5; - Follicular monitoring beginning 4 days later; - GnRH antagonist (citrorelix) when lead follicles 13–14 mm; - Randomized to; (a) same starting dose of rFSH; (b) addition of 75 IU rFSH at night for at least 2 days; - Ovulation induction with hCG | Age: Mean (SD): Constant dose 31.8 (3.1); step-up 31.4 (3.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - ≤ 37 years; - Undergoing IVF/ET; Exclusion criteria:; - PCOS; - BMI > 33; - Day 3 FSH > 14.1 mIU/mL; - History of poor response; - Untreated submucosal polyps, fibroids, hydrosalpinges | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Propst, Bates, Robinson, et al., 2006 #55060 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Propst, Bates, Robinson, et al., 2006 #55060 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Step-up | 18 | 12 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Propst, Bates, Robinson, et al., 2006 #55060 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Constant dose | 21 | 9 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Propst, Bates, Robinson, et al., 2006 #55060 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | 39 | 21 | 60 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Propst, Bates, Robinson, et al., 2006 #55060 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Propst, Bates, Robinson, et al., 2006 #55060 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.86 | 0.59 | 1.25 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Propst, Bates, Robinson, et al., 2006 #55060 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Propst, Bates, Robinson, et al., 2006 #55060 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Propst, Bates, Robinson, et al., 2006 #55060 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Step-up | 18 | 12 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Propst, Bates, Robinson, et al., 2006 #55060 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Constant dose | 17 | 13 | 30 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Propst, Bates, Robinson, et al., 2006 #55060 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | 35 | 25 | 60 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Propst, Bates, Robinson, et al., 2006 #55060 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: +
Rel risk | 1.06 | 0.69 | 1.62
Propst, Hill, Ginsburg, et al., 2001 #58470 | Geographical location: Boston, MA Study dates: Oct 1998–Dec 1999 Size of population (no. of patients): 201 Number of cycles analyzed: 201 Number of cycles per patient: 1.0 Study type: RCT Interventions: Crinone 8% gel vs.IM progesterone | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 30% Endometriosis: 9% Male factor: 26% Tubal factor: 24% PCOS: 10% Inclusion criteria: Undergoing IVF Exclusion criteria:; - Donor oocytes; - Cryopreserved embryos | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: Study stopped early because of excess vaginal bleeding in gel arm Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Propst, Hill, Ginsburg, et al., 2001 #58470 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: Study stopped early because of excess vaginal bleeding in gel arm Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Propst, Hill, Ginsburg, et al., 2001 #58470 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Gel | 31 | 71 | 102 | Comments: Study stopped early because of excess vaginal bleeding in gel arm Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Propst, Hill, Ginsburg, et al., 2001 #58470 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | IM | 48 | 51 | 99 | Comments: Study stopped early because of excess vaginal bleeding in gel arm Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Propst, Hill, Ginsburg, et al., 2001 #58470 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Total | 79 | 122 | 201 | Comments: Study stopped early because of excess vaginal bleeding in gel arm Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Propst, Hill, Ginsburg, et al., 2001 #58470 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Study stopped early because of excess vaginal bleeding in gel arm Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Propst, Hill, Ginsburg, et al., 2001 #58470 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.63 | 0.44 | 0.90 | Comments: Study stopped early because of excess vaginal bleeding in gel arm Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Propst, Hill, Ginsburg, et al., 2001 #58470 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | 2) Live birth: | | | | Comments: Study stopped early because of excess vaginal bleeding in gel arm Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Propst, Hill, Ginsburg, et al., 2001 #58470 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Live birth + | Live birth - | Total | Comments: Study stopped early because of excess vaginal bleeding in gel arm Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Propst, Hill, Ginsburg, et al., 2001 #58470 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Gel | 25 | 77 | 102 | Comments: Study stopped early because of excess vaginal bleeding in gel arm Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Propst, Hill, Ginsburg, et al., 2001 #58470 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | IM | 39 | 60 | 99 | Comments: Study stopped early because of excess vaginal bleeding in gel arm Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Propst, Hill, Ginsburg, et al., 2001 #58470 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | Total | 64 | 137 | 201 | Comments: Study stopped early because of excess vaginal bleeding in gel arm Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Propst, Hill, Ginsburg, et al., 2001 #58470 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Study stopped early because of excess vaginal bleeding in gel arm Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.62 | 0.41 | 0.95
Qublan, Amarin, Tahat, et al., 2006 #55080 | Geographical location: Irbid, Jordan Study dates: Jan 2002–Dec 2003 Size of population (no. of patients): 122 Number of cycles analyzed: 122 (cancelled cycles not included in analysis in paper) Number of cycles per patient: 1.00 Study type: RCT Interventions:; - Long GnRH agonist protocol; - Ultrasound on 3^rd^ day of bleeding after start of GnRH agonist; - If cyst detected, randomized to aspiration or no treatment | Age: Mean (SD): 31.8 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 4 (3.3%) Endometriosis: 23 (18.8%) Male factor: 35 (28.7%) Tubal factor: 14 (11.4%) PCOS: 17 (13.9%) Inclusion criteria: functional ovarian cyst ( thin-walled intraovarian sonolucent structure with a mean diameter of ≥15 mm and E2 levels of ≥50 pg/) on day 3 of bleeding after GnRH administration Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy, intention-to-treat: | | | | Comments:; - Randomization scheme unclear- ?intentional 2:1; - Overall pregnancy rate in patients with cysts considerably lower than rate in patients without cysts (29%); Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: -
Qublan, Amarin, Tahat, et al., 2006 #55080 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Qublan, Amarin, Tahat, et al., 2006 #55080 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Cyst aspiration | 6 | 70 | 76
Qublan, Amarin, Tahat, et al., 2006 #55080 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Control | 3 | 43 | 46
Qublan, Amarin, Tahat, et al., 2006 #55080 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 9 | 113 | 122
Qublan, Amarin, Tahat, et al., 2006 #55080 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 1.21 | 0.32 | 4.61
Quinn and Cooke, 2004 #13070 | Geographical location: Sydney, Australia Study dates: NR Size of population (no. of patients): 60 Number of cycles analyzed: 60 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to media optimized to maintain pH of 7.2 to 7.3 at 1 atmosphere with (a) 6% CO2 vs (b) 5% CO2 | Age: Mean (SD): 32.7 (3.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria:; - Age ≥ 40 years; - No embryos generated; - Testicular/surgically retrieved sperm | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: Minimal difference to determine non-inferiority not stated Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Quinn and Cooke, 2004 #13070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: Minimal difference to determine non-inferiority not stated Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Quinn and Cooke, 2004 #13070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 5% CO2 | 17 | 13 | 30 | Comments: Minimal difference to determine non-inferiority not stated Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Quinn and Cooke, 2004 #13070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 6% CO2 | 13 | 17 | 30 | Comments: Minimal difference to determine non-inferiority not stated Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Quinn and Cooke, 2004 #13070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 30 | 30 | 60 | Comments: Minimal difference to determine non-inferiority not stated Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Quinn and Cooke, 2004 #13070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Minimal difference to determine non-inferiority not stated Quality assessment: Randomization method: Blinding: Dropout rate < 20%: Adequacy of randomization concealment:
Rel risk | 1.31 | 0.78 | 2.19
Ragni, Alagna, Brigante, et al., 2004 #14240 | Geographical location: Milan, Italy Study dates: 9/01–5/02 Size of population: 66 Number of cycles analyzed: 66 Number of cycles per patient: 1.00 Study type: RCT Interventions: Compare to different dosage of Gonadotropins use for GnRH antagonist protocol in pts undergoing IUI. Study divided in to 2 grps Gr A. Receive 50 units of rFSH daily. Gr. B. Receive 50 units of rFSH on alternate day. | Age: Mean (SD):; A 33.1 (3.0); B 32.2 (6.6); Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility:; A 68.8; B 64.7; Endometriosis: NR Male factor:; A 12.5; B 11.8; Tubal factor: NR PCOS: NR Other (specify): Mixed; A 15.6; B 17.6; Other (endometriosis and PCOS); A 3.1; B 5.9; Inclusion criteria:; 1 Unexplained infertility or mild male factor; 2 Infertility last longer than 24 mos; 3 Age<38 yo; 4 BMI 19–30; 5 Normal prolactin, TSH; 6 Normal uterine cavity and bilateral tubal patency.; 7 Pt with endometriosis stage I or II who has at least 6 mo of treatment.; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ragni, Alagna, Brigante, et al., 2004 #14240 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Out + | Out - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ragni, Alagna, Brigante, et al., 2004 #14240 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Daily rFSH | 11 | 21 | 32 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ragni, Alagna, Brigante, et al., 2004 #14240 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Alternate day FSH | 2 | 32 | 34 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ragni, Alagna, Brigante, et al., 2004 #14240 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 13 | 53 | 66 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Ragni, Alagna, Brigante, et al., 2004 #14240 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
RR | 5.84 | 1.40 | 24.35
Rama Raju, Shashi Kumari, Krishna, et al., 2006 #55160 | Geographical location: Andrha Pradesh, India Study dates: Jan 2002–Feb 2005 Size of population (no. of patients): 520 Number of cycles analyzed: 520 Number of cycles per patient: 1.00 Study type: RCT Interventions: Randomized; - Office hysteroscopy with treatment of diagnosed abnormalities (37% of group), followed by repeat IVF or ICSI; - No hysteroscopy, repeat IVF or ICSI; - Long protocol COH | Age: Range: 26–30 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Endometriosis: 36% Male factor: 32% Tubal factor: 17% PCOS: 45% Inclusion criteria:; - 2 or more previous failed IVF cycles; - primary infertility; - normal hysterosalpingogram; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments:; - Prevalence of abnormalities in patients with 2 prior failed cycles may be higher than in all women undergoing initial evaluation1; Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Rama Raju, Shashi Kumari, Krishna, et al., 2006 #55160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Rama Raju, Shashi Kumari, Krishna, et al., 2006 #55160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Office hysteroscopy | 109 | 146 | 255
Rama Raju, Shashi Kumari, Krishna, et al., 2006 #55160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Control | 69 | 196 | 265
Rama Raju, Shashi Kumari, Krishna, et al., 2006 #55160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | 178 | 342 | 520
Rama Raju, Shashi Kumari, Krishna, et al., 2006 #55160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rama Raju, Shashi Kumari, Krishna, et al., 2006 #55160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.64 | 1.28 | 2.10
Rama Raju, Shashi Kumari, Krishna, et al., 2006 #55160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | 2) Live birth:
Rama Raju, Shashi Kumari, Krishna, et al., 2006 #55160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Rama Raju, Shashi Kumari, Krishna, et al., 2006 #55160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Office hysteroscopy | 72 | 183 | 255
Rama Raju, Shashi Kumari, Krishna, et al., 2006 #55160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Control | 44 | 221 | 265
Rama Raju, Shashi Kumari, Krishna, et al., 2006 #55160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | 116 | 404 | 520
Rama Raju, Shashi Kumari, Krishna, et al., 2006 #55160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rama Raju, Shashi Kumari, Krishna, et al., 2006 #55160 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.70 | 1.22 | 2.37
3) Pathology found in 95/255 (37.2%) of hysteroscopy group
Rhodes, Higdon, and Boone, 2007 #55240 | Geographical location: Greenville, SC Study dates: Sep 2003–Oct 2005 Size of population (no. of patients): 99 (1 randomized subject not analyzed due to non-study catheter use) Number of cycles analyzed: 99 Number of cycles per patient: 1.00 Study type: RCT Interventions:; - All embryos transferred on day 3 after assisted hatching; - Edwards-Wallace or Cook catheter used for transfer | Age (mean [SD]): E-W: 33.0 (4.3) Cook: 32.0 (4.3) Race/ethnicity (n [%]): Caucasian: 79 (79%) African-American: 9 (9%) Asian: 11 (11%) Diagnoses (n [%]): Endometriosis: 20 (20.0%) Male factor: 15 (15.2%) Tubal factor: 12 (12.1%) PCOS: 9 (9%) Combination or “other”: 43 (43%) Inclusion criteria: Age < 40; BMI 20–35; fresh sperm or oocytes; 3 or more embryos for transfer; no previous ART Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on transvaginal U/S at 6–7 weeks Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Rhodes, Higdon, and Boone, 2007 #55240 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on transvaginal U/S at 6–7 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Rhodes, Higdon, and Boone, 2007 #55240 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on transvaginal U/S at 6–7 weeks Live birth: NR Multiples: NR Complications: NR | E-W | 29 | 21 | 50 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Rhodes, Higdon, and Boone, 2007 #55240 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on transvaginal U/S at 6–7 weeks Live birth: NR Multiples: NR Complications: NR | Cooke | 31 | 18 | 49 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Rhodes, Higdon, and Boone, 2007 #55240 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on transvaginal U/S at 6–7 weeks Live birth: NR Multiples: NR Complications: NR | | 60 | 39 | 99 | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Rhodes, Higdon, and Boone, 2007 #55240 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on transvaginal U/S at 6–7 weeks Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: - (NR) Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: - (NR)
Rel risk | 0.92 | 0.67 | 1.26
Rickes, Nickel, Kropf, et al., 2002 #58500 | Geographical location: Magdeburg, Germany Study dates: May 1999–May 2001 Size of population (no. of patients): 110 Number of cycles analyzed: 110 Number of cycles per patient: 1.0 Study type: RCT Interventions: Post-surgery for stage II–IV endometriosis, randomized to (a) 6 months GnRH agonist followed by 3 cycles ART, or (b) immediate therapy with 3 cycles ART ART - IUI, IVF, or ICSI | Age: Range: 23–40 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Endometriosis: 100% Inclusion criteria: Stage II–IV endometriosis Exclusion criteria:; - Lack of desire to conceive; - Age > 40; - Dependence on testicular sperm in ART | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy, IUI: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rickes, Nickel, Kropf, et al., 2002 #58500 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rickes, Nickel, Kropf, et al., 2002 #58500 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | GnRH agonist | 24 | 3 | 27 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rickes, Nickel, Kropf, et al., 2002 #58500 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | No Rx | 22 | 14 | 36 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rickes, Nickel, Kropf, et al., 2002 #58500 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Total | 46 | 17 | 63 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rickes, Nickel, Kropf, et al., 2002 #58500 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rickes, Nickel, Kropf, et al., 2002 #58500 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.45 | 1.09 | 1.95 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rickes, Nickel, Kropf, et al., 2002 #58500 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | 2) Pregnancy, IVF/ICSI: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rickes, Nickel, Kropf, et al., 2002 #58500 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rickes, Nickel, Kropf, et al., 2002 #58500 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | GnRH agonist | 21 | 7 | 28 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rickes, Nickel, Kropf, et al., 2002 #58500 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | No Rx | 9 | 10 | 19 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rickes, Nickel, Kropf, et al., 2002 #58500 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | Total | 30 | 17 | 47 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rickes, Nickel, Kropf, et al., 2002 #58500 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.58 | 0.94 | 2.66
Rombauts, Healy, Norman, et al., 2006 #58510 | Geographical location: Woodville, Australia Study dates: NR Size of population (no. of patients): 234 Number of cycles analyzed: 234 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to; (a) GnRH agonist long protocol; (b) ganirelix alone; (c) ganirelix after 2–4 weeks oral contraceptive treatment | Age: Mean (SD): Agonist: 32.2 (4.0) Antagonist: 32.1 (3.7) Antag + OCP: 32.7 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 69 (20.8%) Endometriosis: 25 (7.5%) Male factor: 127 (38.2%) Tubal factor: 69 (20.8%) Combined: 15 (4.5%) Inclusion criteria:; - Healthy females of infertile couples; - Age at time of screening 18–39; - BMI 18–29 kg/m^2^; - Body weight ≤ 90 kg; - Normal menstrual cycle with a range of 24–35 days and an intra-individual variation of < 3 days; Exclusion criteria:; - Contraindications for the use of gonadotrophins; - Endocrine abnormalities (e.g., PCOS); - > 3 unsuccessful controlled ovarian stimulation cycles; - History of low or no ovarian responseduring FSH/HMG treatment; - Clinically relevant abnormal laboratory values (including hormones) or medical examination findings | Definition(s) of outcome(s): Pregnancy: Ultrasound 12–16 weeks after transfer Live birth: NR Multiples: NR Complications: Side effects, OHSS | 1) Pregnancy (per randomized subject), GnRH agonist vs.antagonist alone: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rombauts, Healy, Norman, et al., 2006 #58510 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound 12–16 weeks after transfer Live birth: NR Multiples: NR Complications: Side effects, OHSS | | Preg+ | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rombauts, Healy, Norman, et al., 2006 #58510 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound 12–16 weeks after transfer Live birth: NR Multiples: NR Complications: Side effects, OHSS | Antag | 23 | 94 | 117 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rombauts, Healy, Norman, et al., 2006 #58510 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound 12–16 weeks after transfer Live birth: NR Multiples: NR Complications: Side effects, OHSS | Agonist | 26 | 91 | 117 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rombauts, Healy, Norman, et al., 2006 #58510 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound 12–16 weeks after transfer Live birth: NR Multiples: NR Complications: Side effects, OHSS | Total | 49 | 185 | 234 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rombauts, Healy, Norman, et al., 2006 #58510 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound 12–16 weeks after transfer Live birth: NR Multiples: NR Complications: Side effects, OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rombauts, Healy, Norman, et al., 2006 #58510 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound 12–16 weeks after transfer Live birth: NR Multiples: NR Complications: Side effects, OHSS | Rel risk | 0.88 | 0.54 | 1.46 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rombauts, Healy, Norman, et al., 2006 #58510 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound 12–16 weeks after transfer Live birth: NR Multiples: NR Complications: Side effects, OHSS | 2) Pregnancy (per randomized subject), GnRH agonist vs.antagonist + OCP: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rombauts, Healy, Norman, et al., 2006 #58510 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound 12–16 weeks after transfer Live birth: NR Multiples: NR Complications: Side effects, OHSS | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rombauts, Healy, Norman, et al., 2006 #58510 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound 12–16 weeks after transfer Live birth: NR Multiples: NR Complications: Side effects, OHSS | Antag + OCP | 18 | 99 | 117 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rombauts, Healy, Norman, et al., 2006 #58510 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound 12–16 weeks after transfer Live birth: NR Multiples: NR Complications: Side effects, OHSS | Agonist | 26 | 91 | 117 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rombauts, Healy, Norman, et al., 2006 #58510 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound 12–16 weeks after transfer Live birth: NR Multiples: NR Complications: Side effects, OHSS | Total | 44 | 190 | 234 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rombauts, Healy, Norman, et al., 2006 #58510 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound 12–16 weeks after transfer Live birth: NR Multiples: NR Complications: Side effects, OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rombauts, Healy, Norman, et al., 2006 #58510 | | | Definition(s) of outcome(s): Pregnancy: Ultrasound 12–16 weeks after transfer Live birth: NR Multiples: NR Complications: Side effects, OHSS | Rel risk | 0.69 | 0.40 | 1.19 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
3) Fewer side effects in ganirellix group, lower OHSS (but only 12 total)
Rufas-Sapir, Stein, Orvieto, et al., 2004 #12760 | Geographical location: Tel Aviv, Israel Study dates: NR Size of population (no. of patients): 207 Number of cycles analyzed: 207 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to (a) control vs (b) mechanical hatching (day 2–3) | Age: Range: < 35: 34.8%; 35–40: 35.7%; >40: 29.5% Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ≥ 3 previous failed cycles Normal menses Normal endocrine/anatomical evaluation Exclusion criteria: Male factor Recurrent abortion Clinically relevant systemic disease | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound with + hCG Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rufas-Sapir, Stein, Orvieto, et al., 2004 #12760 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound with + hCG Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rufas-Sapir, Stein, Orvieto, et al., 2004 #12760 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound with + hCG Live birth: NR Multiples: NR Complications: NR | Assisted hatching | 22 | 82 | 104 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rufas-Sapir, Stein, Orvieto, et al., 2004 #12760 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound with + hCG Live birth: NR Multiples: NR Complications: NR | Control | 28 | 75 | 103 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rufas-Sapir, Stein, Orvieto, et al., 2004 #12760 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound with + hCG Live birth: NR Multiples: NR Complications: NR | | 50 | 157 | 207 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rufas-Sapir, Stein, Orvieto, et al., 2004 #12760 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound with + hCG Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rufas-Sapir, Stein, Orvieto, et al., 2004 #12760 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound with + hCG Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.78 | 0.48 | 1.27 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
2) Pregnancy rates significantly lower with assisted hatching in women < 35 (15% vs 35%); higher with hatching in women 41 and older (30% vs 22%)
Sagoskin, Levy, Tucker, et al., 2007 #55380 | Geographical location: Rockville, MD Study dates: Aug 2001–March 2005 Size of population (no. of patients): 199 (4 not analyzed due to protocol violation (3) or loss to follow-up (1) Number of cycles analyzed: 199 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to (a) control or (b) laser assisted hatching | Age: Mean: 34.0 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - first or second autologous IVF-embryo transfer cycles; - Age < 40; - maximum baseline FSH 10 mIU/mL,; - maximum baseline E2 75 pg/mL,; - ovulatory menstrual cycles,; - no uterine abnormality or communicating hydrosalpinx,; - good embryo quality.; Exclusion criteria:; - diminished ovarian reserve, (PCOS),; - uterine or egg factor infertility; - >1 previous unsuccessful IVF attempt | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac with +FHR Live birth: Yes Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: 2:1 randomization reported, but ratio of active: control 1.5 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sagoskin, Levy, Tucker, et al., 2007 #55380 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac with +FHR Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: 2:1 randomization reported, but ratio of active: control 1.5 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sagoskin, Levy, Tucker, et al., 2007 #55380 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac with +FHR Live birth: Yes Multiples: NR Complications: NR | Hatching | 63 | 55 | 118 | Comments: 2:1 randomization reported, but ratio of active: control 1.5 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sagoskin, Levy, Tucker, et al., 2007 #55380 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac with +FHR Live birth: Yes Multiples: NR Complications: NR | Control | 44 | 37 | 81 | Comments: 2:1 randomization reported, but ratio of active: control 1.5 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sagoskin, Levy, Tucker, et al., 2007 #55380 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac with +FHR Live birth: Yes Multiples: NR Complications: NR | | 107 | 92 | 199 | Comments: 2:1 randomization reported, but ratio of active: control 1.5 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sagoskin, Levy, Tucker, et al., 2007 #55380 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac with +FHR Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: 2:1 randomization reported, but ratio of active: control 1.5 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sagoskin, Levy, Tucker, et al., 2007 #55380 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac with +FHR Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.98 | 0.76 | 1.28 | Comments: 2:1 randomization reported, but ratio of active: control 1.5 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sagoskin, Levy, Tucker, et al., 2007 #55380 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac with +FHR Live birth: Yes Multiples: NR Complications: NR | 2) Live birth: | | | | Comments: 2:1 randomization reported, but ratio of active: control 1.5 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sagoskin, Levy, Tucker, et al., 2007 #55380 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac with +FHR Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: 2:1 randomization reported, but ratio of active: control 1.5 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sagoskin, Levy, Tucker, et al., 2007 #55380 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac with +FHR Live birth: Yes Multiples: NR Complications: NR | Study drug | 55 | 63 | 118 | Comments: 2:1 randomization reported, but ratio of active: control 1.5 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sagoskin, Levy, Tucker, et al., 2007 #55380 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac with +FHR Live birth: Yes Multiples: NR Complications: NR | Control | 37 | 44 | 81 | Comments: 2:1 randomization reported, but ratio of active: control 1.5 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sagoskin, Levy, Tucker, et al., 2007 #55380 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac with +FHR Live birth: Yes Multiples: NR Complications: NR | | 92 | 107 | 199 | Comments: 2:1 randomization reported, but ratio of active: control 1.5 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sagoskin, Levy, Tucker, et al., 2007 #55380 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: gestational sac with +FHR Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: 2:1 randomization reported, but ratio of active: control 1.5 Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 1.02 | 0.75 | 1.39
Sauer, Thornton, Schoolcraft, et al., 2004 #11070 | Geographical location: NY, NY; Engelwood CO; Providence, RI Study dates: NR Size of population (no. of patients): 74 Number of cycles analyzed: 74 Number of cycles per patient: 1 Study type: RCT Interventions: Group A: leuprolide acetate (Lupron®: TAP Pharmaceuticals) for pituitary downregulation and r-hFSH (Gonal-f® in multi-dose vials of 450 IU or 1050 IU: Serono Inc.) for ovarian stimulation. Group B: Cetrorelix (Cetrotide®: Serono Inc.) for down-regulation and r-hFSH for ovarian stimulation. Group C: Cetrorelix and r-hFSH together with mid-cycle r-hLH (Luveris®; Serono). | Age: Mean (SD): 32.6 (4) Range: 22 – 39 Race/ethnicity (n [%]): Caucasian: 51/73 (69.9%) Diagnoses (n [%]): Male factor: 56/73 (76.7%) Tubal factor: 18/73 (24.7%) Inclusion criteria: All of the following criteria were satisfied within three menstrual cycles prior to randomization: regular menstrual cycles, body mass index (BMI) < 35 kg/m-. both ovaries present, no clinical signs of pelvic or uterine abnormalities, normal cervical cytology, washout period completed for any previous IVF drug protocols and FSH concentrations in the normal range. All women were also required to be willing and able to comply with the study protocol. Exclusion criteria: Clinically significant systemic disease, HIV, hepatitis C or B, presence of endometriosis or medical conditions likely to interfere with the study drug, previous assisted reproduction cycles had failed through insufficient response to gonadotrophin stimulation or absence of motile spermatozoa, or if ≥ 3 consecutive assisted reproduction cycles without a clinical pregnancy, or had a history of extrauterine pregnancy or abnormal gynecological bleeding. | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - (open label) Dropout rate < 20%: Adequacy of randomization concealment: - (open label)
Sauer, Thornton, Schoolcraft, et al., 2004 #11070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | Clin preg + | Clin preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - (open label) Dropout rate < 20%: Adequacy of randomization concealment: - (open label)
Sauer, Thornton, Schoolcraft, et al., 2004 #11070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Leuprolide | 11 | 14 | 25 | Comments: None Quality assessment: Randomization method: + Blinding: - (open label) Dropout rate < 20%: Adequacy of randomization concealment: - (open label)
Sauer, Thornton, Schoolcraft, et al., 2004 #11070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Cetrorelix | 21 | 28 | 49 | Comments: None Quality assessment: Randomization method: + Blinding: - (open label) Dropout rate < 20%: Adequacy of randomization concealment: - (open label)
Sauer, Thornton, Schoolcraft, et al., 2004 #11070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Total | 32 | 42 | 74 | Comments: None Quality assessment: Randomization method: + Blinding: - (open label) Dropout rate < 20%: Adequacy of randomization concealment: - (open label)
Sauer, Thornton, Schoolcraft, et al., 2004 #11070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - (open label) Dropout rate < 20%: Adequacy of randomization concealment: - (open label)
Sauer, Thornton, Schoolcraft, et al., 2004 #11070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 1.03 | 0.59 | 1.78 | Comments: None Quality assessment: Randomization method: + Blinding: - (open label) Dropout rate < 20%: Adequacy of randomization concealment: - (open label)
Sauer, Thornton, Schoolcraft, et al., 2004 #11070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | By the three groups: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - (open label) Dropout rate < 20%: Adequacy of randomization concealment: - (open label)
Sauer, Thornton, Schoolcraft, et al., 2004 #11070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Group A: 11/25 | | | | Comments: None Quality assessment: Randomization method: + Blinding: - (open label) Dropout rate < 20%: Adequacy of randomization concealment: - (open label)
Sauer, Thornton, Schoolcraft, et al., 2004 #11070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Group B: 11/25 | | | | Comments: None Quality assessment: Randomization method: + Blinding: - (open label) Dropout rate < 20%: Adequacy of randomization concealment: - (open label)
Sauer, Thornton, Schoolcraft, et al., 2004 #11070 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Group C: 10/24 | | | | Comments: None Quality assessment: Randomization method: + Blinding: - (open label) Dropout rate < 20%: Adequacy of randomization concealment: - (open label)
2) One patient in each treatment group had OHSS.
Sbracia, Farina, Poverini, et al., 2005 #40220 | Geographical location: Rome, Italy Study dates: 1/99 – 7/2001 Size of population: Grp 1: short protocol, 110 Grp 2: long protocol, 110 Number of cycles analyzed: 220 Number of cycles per patient: 1.00 Study type: RCT Interventions: Women undergoing first ICSI cycle age ≥ 40 randomized to short protocol with a GnRH agonist vs long protocol with a GnRH agonist. Used buserelin and FSH | Age: Grp 1: Mean (SD): 41.6 [1.4] Grp 2: Mean (SD): 42.4 [1.5] Race/ethnicity (n [%]): NR Diagnoses (n [%]): Grp 1: Unexplained infertility: 35 [12.8] Endometriosis: 6 [12.8] Male factor: 46 [41] Tubal factor: 19 [23.1] PCOS: 4 [10.2] Grp 2: Unexplained infertility: 36 [19.3] Endometriosis: 4 [12.9] Male factor: 49 [29.0] Tubal factor: 13 [22.6]] PCOS: 5 [16.1] Inclusion criteria: Age ≥ 40, day 3 FSH ≤ 10 and E2 ≤ 60, first cycle, all nulliparous Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac Live birth: NR Multiples: NR Complications: NR | 1) Pg rate grp 1 vs 2: | | | | Comments: None Quality assessment: Randomization method: NR Blinding: NO Dropout rate < 20%: + Adequacy of randomization concealment: NO
Sbracia, Farina, Poverini, et al., 2005 #40220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac Live birth: NR Multiples: NR Complications: NR | | preg + | preg neg | Total | Comments: None Quality assessment: Randomization method: NR Blinding: NO Dropout rate < 20%: + Adequacy of randomization concealment: NO
Sbracia, Farina, Poverini, et al., 2005 #40220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac Live birth: NR Multiples: NR Complications: NR | Grp 1 | 12 | 98 | 110 | Comments: None Quality assessment: Randomization method: NR Blinding: NO Dropout rate < 20%: + Adequacy of randomization concealment: NO
Sbracia, Farina, Poverini, et al., 2005 #40220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac Live birth: NR Multiples: NR Complications: NR | Grp 2 | 25 | 85 | 110 | Comments: None Quality assessment: Randomization method: NR Blinding: NO Dropout rate < 20%: + Adequacy of randomization concealment: NO
Sbracia, Farina, Poverini, et al., 2005 #40220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac Live birth: NR Multiples: NR Complications: NR | Total | 37 | 183 | 220 | Comments: None Quality assessment: Randomization method: NR Blinding: NO Dropout rate < 20%: + Adequacy of randomization concealment: NO
Sbracia, Farina, Poverini, et al., 2005 #40220 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: NR Blinding: NO Dropout rate < 20%: + Adequacy of randomization concealment: NO
Rel risk | 0.48 | 0.25 | 0.91
Schats, Sutter, Bassil, et al., 2000 #7390 | Geographical location: Multicenter:; - Amsterdam, The Netherlands; - Gent, Belgium; - Brussels, Belgium; - Nijmegen, The Netherlands; Study dates: 11/96 – 8/98 Size of population: 496 Number of cycles analyzed: 496 Number of cycles per patient: 1.00 Study type: RCT Interventions: Compare the efficacy of rFSH (Gonal-F) and highly purified urine hFSH (Metrodin HP) in women undergoing ovarian stimulation for IVF/ICSI. | Age: Mean (SD): Gonal-F 31.4 (3.4) Metrodin 31.3 (3.7) Range: 18–38 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 50 Tubal factor: 23 Inclusion criteria:; - Regular, spontaneous menstrual cycle of 25d–35d; - Aged 18–38; - Infertility attributable to any of the following criteria; - Tubal factor; - Grade I/II endometriosis; - Male factor; - Unexplained infertility; - Normal FSH and LH; - Prolactin < 20 ng/ml; - Testosterone<3.5 nmol/l; - No more than 2 previous ART cycles; - BMI > or = 18 but < or=28; - Presence of both ovaries and normal uterine cavity; - No treatment with clomiphene citrate or gonadotrophins in the mo prior to the study; - Willing to participate in the study and to comply with procedures.; Exclusion criteria:; - Abnormal gyn bleeding of undetermined origin Previous IVF or ICSI failure due to a poor response to gonadotropins or a previous ICSI failure due to problems of sperm fertilization; - previous history of severe OHHS; - A male partner with azoospermia and clinical signs of infection detected in a semen analysis within the past 12 mos; - A clinically significant condition/disease; - Microsurgical epididymal sperm aspiration, testicular sperm extraction or percutaneous epididymal sperm aspiration procedures | Definition(s) of outcome(s): Pregnancy rate: Positive pregnancy test Live birth: NR Multiples: Yes Complications: NR | 1) Delivery rate: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Schats, Sutter, Bassil, et al., 2000 #7390 | | | Definition(s) of outcome(s): Pregnancy rate: Positive pregnancy test Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Schats, Sutter, Bassil, et al., 2000 #7390 | | | Definition(s) of outcome(s): Pregnancy rate: Positive pregnancy test Live birth: NR Multiples: Yes Complications: NR | hp_uFSH | 43 | 206 | 249 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Schats, Sutter, Bassil, et al., 2000 #7390 | | | Definition(s) of outcome(s): Pregnancy rate: Positive pregnancy test Live birth: NR Multiples: Yes Complications: NR | rFSH | 56 | 191 | 247 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Schats, Sutter, Bassil, et al., 2000 #7390 | | | Definition(s) of outcome(s): Pregnancy rate: Positive pregnancy test Live birth: NR Multiples: Yes Complications: NR | | 99 | 397 | 496 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Schats, Sutter, Bassil, et al., 2000 #7390 | | | Definition(s) of outcome(s): Pregnancy rate: Positive pregnancy test Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Schats, Sutter, Bassil, et al., 2000 #7390 | | | Definition(s) of outcome(s): Pregnancy rate: Positive pregnancy test Live birth: NR Multiples: Yes Complications: NR | Rel risk | 0.76 | 0.53 | 1.09 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Schats, Sutter, Bassil, et al., 2000 #7390 | | | Definition(s) of outcome(s): Pregnancy rate: Positive pregnancy test Live birth: NR Multiples: Yes Complications: NR | 2) Multiple pregnancies: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Schats, Sutter, Bassil, et al., 2000 #7390 | | | Definition(s) of outcome(s): Pregnancy rate: Positive pregnancy test Live birth: NR Multiples: Yes Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Schats, Sutter, Bassil, et al., 2000 #7390 | | | Definition(s) of outcome(s): Pregnancy rate: Positive pregnancy test Live birth: NR Multiples: Yes Complications: NR | rFSH | 16 | 46 | 62 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Schats, Sutter, Bassil, et al., 2000 #7390 | | | Definition(s) of outcome(s): Pregnancy rate: Positive pregnancy test Live birth: NR Multiples: Yes Complications: NR | Control | 19 | 31 | 50 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Schats, Sutter, Bassil, et al., 2000 #7390 | | | Definition(s) of outcome(s): Pregnancy rate: Positive pregnancy test Live birth: NR Multiples: Yes Complications: NR | | 35 | 77 | 112 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Schats, Sutter, Bassil, et al., 2000 #7390 | | | Definition(s) of outcome(s): Pregnancy rate: Positive pregnancy test Live birth: NR Multiples: Yes Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.68 | 0.39 | 1.18
Scholtes, Schnittert, van Hoogstraten, et al., 2004 #13440 | Geographical location: Dusseldorf, Germany Study dates: NR Size of population (no. of patients): 102 Number of cycles analyzed: 102 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - Long protocol GnRH agonist downregulation; - Randomized to; (a) 450 IU rFSH every 3 days, or; (b) 150 IU rFSH every day; Dose adjusted in both groups starting day 6 Ovulation triggered when at least 1 follicle 18 mm, 2 or more 16 mm | Age: Mean (SD): Daily 30.7; q 3 days 31.6 Range: 19–39 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 93 (91.1%) Tubal factor: 13 (12.7%) Inclusion criteria:; - no more than three previous IVF/ICSI treatment cycles,; - menstrual cycle of ≤35 days; - no previous ovarian surgery; - BMI ≤ 30; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
Scholtes, Schnittert, van Hoogstraten, et al., 2004 #13440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
Scholtes, Schnittert, van Hoogstraten, et al., 2004 #13440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Every 3 days | 13 | 38 | 51 | Comments: None Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
Scholtes, Schnittert, van Hoogstraten, et al., 2004 #13440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Daily | 7 | 44 | 51 | Comments: None Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
Scholtes, Schnittert, van Hoogstraten, et al., 2004 #13440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | 20 | 82 | 102 | Comments: None Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
Scholtes, Schnittert, van Hoogstraten, et al., 2004 #13440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
Scholtes, Schnittert, van Hoogstraten, et al., 2004 #13440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 1.86 | 0.81 | 4.27 | Comments: None Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
Scholtes, Schnittert, van Hoogstraten, et al., 2004 #13440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | 2) OHSS: | | | | Comments: None Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
Scholtes, Schnittert, van Hoogstraten, et al., 2004 #13440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
Scholtes, Schnittert, van Hoogstraten, et al., 2004 #13440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Study drug | 5 | 46 | 51 | Comments: None Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
Scholtes, Schnittert, van Hoogstraten, et al., 2004 #13440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Control | 6 | 45 | 51 | Comments: None Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
Scholtes, Schnittert, van Hoogstraten, et al., 2004 #13440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | 11 | 91 | 102 | Comments: None Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
Scholtes, Schnittert, van Hoogstraten, et al., 2004 #13440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
Scholtes, Schnittert, van Hoogstraten, et al., 2004 #13440 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 0.83 | 0.27 | 2.56 | Comments: None Quality assessment: Randomization method: + Blinding:- Dropout rate < 20%: + Adequacy of randomization concealment: +
3) Biochemical pregnancy rate significantly higher in 3 day dosage group (33.3% vs 15.7%)
Selman, De Santo, Sterzik, et al., 2002 #660 | Geographical location: 3 institutions; - Brindisi, Italy; - Florance, Italy; - Ulm, Germany; Study dates: 12/98 – 11/00 Size of population: 267 Number of cycles analyzed: 267 Number of cycles per patient: 1.00 Study type: RCT Interventions: Compare the effectiveness of highly purify urinary follicle stimulation hormone (Fostimon) and Recombinant FSH (Gonal-F) | Age: Mean (SD): Fostimon: 32 (4) Gonal-F: 31.8 (6) Range: 18–38 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Infertility attributable to tubal factor, male factor, or unexplained infertility; - Normal serum level of FSH, LH and prolactin; - Regular ovulatory cycle every 25–35 days; - Normal uterine cavity; - No treatment with gonadotropins in the month before study entry; - presentation for the first IVF cycle; - BMI >or= 18 but < or= 26; - Willingness to participate in the study and to comply with the procedures; Exclusion criteria:; - Had gynecologic abnormalities or diseases; - Previous poor response to gonadotropins used for IUI; - History of severe OHHS PCOS; - Male partner had azoospermia; - Clinical signs of infection in semen analysis within 12 mo before treatment | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy rate; confirm pregnancy by u/s 6 wks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Selman, De Santo, Sterzik, et al., 2002 #660 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy rate; confirm pregnancy by u/s 6 wks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | | Out + | Out - | Total | Comments: None Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Selman, De Santo, Sterzik, et al., 2002 #660 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy rate; confirm pregnancy by u/s 6 wks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | Highly purified uFSH | 61 | 70 | 131 | Comments: None Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Selman, De Santo, Sterzik, et al., 2002 #660 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy rate; confirm pregnancy by u/s 6 wks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | rFSH | 49 | 84 | 133 | Comments: None Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Selman, De Santo, Sterzik, et al., 2002 #660 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy rate; confirm pregnancy by u/s 6 wks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | | 110 | 154 | 264 | Comments: None Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Selman, De Santo, Sterzik, et al., 2002 #660 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy rate; confirm pregnancy by u/s 6 wks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Selman, De Santo, Sterzik, et al., 2002 #660 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy rate; confirm pregnancy by u/s 6 wks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 1.26 | 0.95 | 1.69 | Comments: None Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Selman, De Santo, Sterzik, et al., 2002 #660 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy rate; confirm pregnancy by u/s 6 wks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Selman, De Santo, Sterzik, et al., 2002 #660 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy rate; confirm pregnancy by u/s 6 wks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | | Out + | Out - | Total | Comments: None Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Selman, De Santo, Sterzik, et al., 2002 #660 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy rate; confirm pregnancy by u/s 6 wks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | fostimon | 52 | 79 | 131 | Comments: None Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Selman, De Santo, Sterzik, et al., 2002 #660 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy rate; confirm pregnancy by u/s 6 wks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | Gonal F | 41 | 92 | 133 | Comments: None Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Selman, De Santo, Sterzik, et al., 2002 #660 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy rate; confirm pregnancy by u/s 6 wks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | | 93 | 171 | 264 | Comments: None Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Selman, De Santo, Sterzik, et al., 2002 #660 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy rate; confirm pregnancy by u/s 6 wks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
Selman, De Santo, Sterzik, et al., 2002 #660 | | | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy rate; confirm pregnancy by u/s 6 wks after embryo transfer Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 1.29 | 0.93 | 1.79 | Comments: None Quality assessment: Randomization method: NR Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment:+
3) There was no difference in multiple pregnancy rates (29.5% vs 22.4%)
Serafini, Yadid, Motta, et al., 2006 #55590 | Geographical location: Sao Paulo and Rio de Janeiro, Brazil Study dates: NR Size of population (no. of patients): 323 Number of cycles analyzed: 323 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - All received rFSH on sliding scale (150–350 IU) based on age; (a) Long protocol GnRH agonist down regulation, rFSH started when E2 ≤60 pg/mL with dose adjusted based on response beginning day 6; (b) rFSH on day 2–3 of menstrual cycle, adding GnRH antagonist (citrorelix) when either 2 follicles 13 mm or day 6; (c) rFSH on day 2–3 of menstrual cycle, adding GnRH antagonist (citrorelix) + 200 IU hCG + decreasing rFSH to 75 IU when either 2 follicles 13 mm or day 6; - Ovulation triggered according to same protocol in all 3 groups | Age: Mean (SD): GnRH agonist: 33.4 (0.3) GnRH antagonist: 34.4 (0.4) Antagonist + hCG: 33.5 (0.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; 1 the presence of a standard indication for either IVF or intracytoplasmic sperm injection (ICSI) treatment;; 2 age 21 to 39 years;; 3 the presence of two functional ovaries;; 4 the presence of an anatomically normal uterine cavity on the basis of recent hysterosalpingographic or hysteroscopic evaluation (≤6 months);; 5 history of ≤3 attempts at IVF/ICSI;; 6 early follicular phase (day 2 or 3) serum FSH levels ≤15 IU/L and E2 levels ≥60 pg/mL;; 7 no history of low ovarian response in previous IVF/ICSI treatment;; 8 body mass index (BMI) ≤25 kg/m2;; 9 no untreated endocrinologic disease;; 10 no treatment with gonadotropin therapy for ≥3 months preceding the study; and; 11 male partner should have ejaculated spermatozoa with ≥1% strict morphology.; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | 1) Clinical pregnancy, GnRH antagonist vs GnRH agonist: | | | | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | Antag | 38 | 55 | 93 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | Agonist | 43 | 55 | 98 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | | 81 | 110 | 191 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 0.93 | 0.67 | 1.30 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | 2 ) Clinical pregnancy, GnRH antagonist + hCG vs GnRH agonist: | | | | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | Antag + hCG | 58 | 48 | 106 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | Agonist | 43 | 55 | 98 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | | 101 | 103 | 204 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 1.25 | 0.94 | 1.66 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | 3) Clinical pregnancy, GnRH antagonist + hCG vs GnRH antagonist only: | | | | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | Antag + hCG | 58 | 48 | 106 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | Antag | 38 | 55 | 93 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | | 96 | 103 | 199 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Serafini, Yadid, Motta, et al., 2006 #55590 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR Live birth: NR Multiples: NR Complications: OHSS | Rel risk | 1.34 | 0.99 | 1.81 | Comments: None Quality assessment: Randomization method:+ Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
4) OHSS 6.1% GnRH agonist, 4.1% antagonist, 2.9% antagonist + hCG outcome]:
Sifer, Sellami, Poncelet, et al., 2006 #55700 | Geographical location: Paris, France Study dates: Jan 2004–Dec 2004 Size of population (no. of patients): 125 Number of cycles analyzed: 125 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to (a) control vs (b) assisted hatching (pronase) | Age: Mean (SD): Control 32.0 (4.4); hatching 32.2 (4.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Endometriosis: 63 (50.4%) Male factor: 20 (24.0%) Tubal factor: 8 (6.4%) Other (not specified): 14 (11.2%) Inclusion criteria: 1^st^ frozen-thawed embryo cycle Exclusion criteria: Donor cycles | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR at 5–6 weeks post-transfer Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: More endometriosis (59% vs 41%) fewer male factor(23% vs 41%) in assisted hatching group Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Sifer, Sellami, Poncelet, et al., 2006 #55700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR at 5–6 weeks post-transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg -
Sifer, Sellami, Poncelet, et al., 2006 #55700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR at 5–6 weeks post-transfer Live birth: NR Multiples: NR Complications: NR | Study drug | 11 | 50 | 61
Sifer, Sellami, Poncelet, et al., 2006 #55700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR at 5–6 weeks post-transfer Live birth: NR Multiples: NR Complications: NR | Control | 12 | 52 | 64
Sifer, Sellami, Poncelet, et al., 2006 #55700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR at 5–6 weeks post-transfer Live birth: NR Multiples: NR Complications: NR | | 23 | 102 | 125
Sifer, Sellami, Poncelet, et al., 2006 #55700 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with + FHR at 5–6 weeks post-transfer Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Rel risk | 0.96 | 0.46 | 2.01
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | Geographical location: 3 hospitals in the Netherlands Study dates: 2/2000 – 2/2002 Size of population: 178 Number of cycles analyzed: 178 Number of cycles per patient: 1.00 Study type: RCT Interventions: Study the effectiveness of 3 GnRH agonist protocol Grp L: Pts received the traditional long protocol: Mid luteal started triptorelin (the study GnRH agonist) was continued up to and including the day of hCG. Grp M: Midluteal started triptorelin and continue up to and including day 4 of hMG administration. Grp S: Stop triptorelin On the day of hMG started. Grp M and S continued treatment with placebo injections from the day after stopping triptorelin up to and including the day of hCG administration | Age: Mean (SD): S: 31.9 (3.0) M: 31.6 (3.6) L: 32.1 (3.6) Range: 18–38 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Eligibility for IVF/ICSI treatment; - History of s spontaneous regular cycle between 24–35 days; - 18–38 yo; - BMI < or = to 32; Exclusion criteria:; - PCOS; - Incipient ovarian failure; - Ovulation induction or IVF/ICS in the 2 mos before this study; - Poor stimulation response in prior cycle; - Treatment with GnRH within 3 mos before the study; - Previous inclusion of this study; - History or suspicion of non compliance to medical regimens; - Treatment with oral contraceptives within 1 mo before this study | Definition(s) of outcome(s): Pregnancy: Positive urine or serum hCG 2–3 with after embryo transfer Ongoing pregnancy: positive pregnancy test at 10–12 wks of gestation Live birth: NR Multiples: NR Complications: Premature LH surge | 1) Pregnancy rate between short and long protocol: | | | | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | | Out + | Out - | Total | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | Short | 17 | 41 | 58 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | Long | 13 | 45 | 58 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | | 30 | 86 | 116 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | Rel risk | 1.31 | 0.70 | 2.44 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | 2) Pregnancy rate between medium and long protocol: | | | | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | | Out + | Out - | Total | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | Medium | 20 | 42 | 62 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | Long | 13 | 44 | 58 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | | 33 | 86 | 119 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | Rel risk | 1.41 | 0.78 | 2.57 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | 3) Ongoing pregnancy rate between short and long protocol: | | | | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | | Out + | Out - | Total | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | Short | 16 | 42 | 58 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | Long | 12 | 46 | 58 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | | 28 | 88 | 116 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | Rel risk | 1.33 | 0.69 | 2.56 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | 4) Ongoing pregnancy rate between medium and long protocol: | | | | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | | Out + | Out - | Total | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | Medium | 15 | 47 | 62 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | Long | 12 | 46 | 58 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | | 27 | 93 | 120 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
Simons, Roelofs, Schmoutziguer, et al., 2005 #9890 | | | | Rel risk | 1.17 | 0.60 | 2.28 | Comments: No adjustments made for multiple comparisons Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%:+ Adequacy of randomization concealment: +
5) NO premature LH surge (which is the main complication that might happen with short and medium protocol) occurred during study.
Smith, Coyle, and Norman, 2006 #55800 | Geographical location: Adelaide, Australia Study dates: May 2003–Jan 2005 Size of population (no. of patients): 228 (pregnancy outcomes available for 221) Number of cycles analyzed: 228 Number of cycles per patient: 1.00 Study type: RCT Interventions:; - 3 sessions of acupuncture (active or sham): day 9 of stimulation, immediately before and immediately after embryo transfer; - acupuncture: administered based on traditional Chinese medicine diagnosis; - sham—acupuncture performed close to, but not on, same points, using blunt placebo needle | Age: Mean (SD): Acupuncture 35.9 (4.7); sham: 36.1 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 51 (22.3%) Endometriosis: 54 (23.7%) Male factor: 105 (46.0%) Tubal factor: 89 (39.0%) Unspecified “other”:82 (36.0%) Inclusion criteria:; - Planned IVF or ICSI; Exclusion criteria:; - Previous cycle in this trial | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Ongoing pregnancy: live fetus at 18 weeks Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Smith, Coyle, and Norman, 2006 #55800 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Ongoing pregnancy: live fetus at 18 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Smith, Coyle, and Norman, 2006 #55800 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Ongoing pregnancy: live fetus at 18 weeks Live birth: NR Multiples: NR Complications: NR | Study drug | 34 | 76 | 110 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Smith, Coyle, and Norman, 2006 #55800 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Ongoing pregnancy: live fetus at 18 weeks Live birth: NR Multiples: NR Complications: NR | Control | 27 | 81 | 108 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Smith, Coyle, and Norman, 2006 #55800 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Ongoing pregnancy: live fetus at 18 weeks Live birth: NR Multiples: NR Complications: NR | | 61 | 157 | 218 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Smith, Coyle, and Norman, 2006 #55800 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Ongoing pregnancy: live fetus at 18 weeks Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Smith, Coyle, and Norman, 2006 #55800 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Ongoing pregnancy: live fetus at 18 weeks Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.24 | 0.80 | 1.90 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Smith, Coyle, and Norman, 2006 #55800 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Ongoing pregnancy: live fetus at 18 weeks Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Smith, Coyle, and Norman, 2006 #55800 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Ongoing pregnancy: live fetus at 18 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Smith, Coyle, and Norman, 2006 #55800 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Ongoing pregnancy: live fetus at 18 weeks Live birth: NR Multiples: NR Complications: NR | Study drug | 31 | 79 | 110 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Smith, Coyle, and Norman, 2006 #55800 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Ongoing pregnancy: live fetus at 18 weeks Live birth: NR Multiples: NR Complications: NR | Control | 22 | 86 | 108 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Smith, Coyle, and Norman, 2006 #55800 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Ongoing pregnancy: live fetus at 18 weeks Live birth: NR Multiples: NR Complications: NR | | 53 | 165 | 218 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Smith, Coyle, and Norman, 2006 #55800 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Ongoing pregnancy: live fetus at 18 weeks Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Smith, Coyle, and Norman, 2006 #55800 | | | Definition(s) of outcome(s): Pregnancy: Fetal heart rate on ultrasound Ongoing pregnancy: live fetus at 18 weeks Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.38 | 0.86 | 2.23 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
3) Relaxation more common in control group; no changes in any of SF-36 domains
Staessen, Platteau, Van Assche, et al., 2004 #58530 | Geographical location: Brussels, Belgium Study dates: Mar 2000–Dec 2003 Size of population (no. of patients): 400 randomized, 289 to oocyte retrieval Number of cycles analyzed: 289 Number of cycles per patient: 1.0 Study type: RCT Interventions: ICSI with blastocyst transfer, randomized to preimplantation genetic diagnosis | Age: Mean (SD): Control: 39.9 (2.4) PGD: 40.1 (2.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 53 (18%) Male factor: 113 (39%) Tubal factor: 57 (20%) Combined: 67 (23%) Inclusion criteria:; - Maternal age ≥ 37; - Need for ICSI; - Motile sperm; - Both partners with a normal karyotype; Exclusion criteria: NR | Definition(s) of outcome(s): Ongoing pregnancy: Gestational sac with FHR 6 weeks post-transfer Live birth: NR Multiples: NR Complications: NR | 1) Ongoing pregnancy: | | | | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Staessen, Platteau, Van Assche, et al., 2004 #58530 | | | Definition(s) of outcome(s): Ongoing pregnancy: Gestational sac with FHR 6 weeks post-transfer Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Staessen, Platteau, Van Assche, et al., 2004 #58530 | | | Definition(s) of outcome(s): Ongoing pregnancy: Gestational sac with FHR 6 weeks post-transfer Live birth: NR Multiples: NR Complications: NR | PGD | 22 | 126 | 148 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Staessen, Platteau, Van Assche, et al., 2004 #58530 | | | Definition(s) of outcome(s): Ongoing pregnancy: Gestational sac with FHR 6 weeks post-transfer Live birth: NR Multiples: NR Complications: NR | Control | 29 | 112 | 141 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Staessen, Platteau, Van Assche, et al., 2004 #58530 | | | Definition(s) of outcome(s): Ongoing pregnancy: Gestational sac with FHR 6 weeks post-transfer Live birth: NR Multiples: NR Complications: NR | Total | 51 | 238 | 289 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Staessen, Platteau, Van Assche, et al., 2004 #58530 | | | Definition(s) of outcome(s): Ongoing pregnancy: Gestational sac with FHR 6 weeks post-transfer Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Staessen, Platteau, Van Assche, et al., 2004 #58530 | | | Definition(s) of outcome(s): Ongoing pregnancy: Gestational sac with FHR 6 weeks post-transfer Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.72 | 0.44 | 1.20 | Comments: Randomization method not described Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
2) Significantly fewer embryos transferred with PGD
Stener-Victorin, Waldenstrom, Wikland, et al., 2003 #16350 | Geographical location: Gothenberg, Malmo, and Stockholm, Sweden Study dates: 1999 to 2001 Size of population (no. of patients): 286 Number of cycles analyzed: 274 Number of cycles per patient: 1 Study type: RCT Interventions: EA and PCB: electoacupuncture plus a paracervical block Alfentanil and PCB | Age: Mean (range): 32.9 (22–38) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 68 (25%) Endometriosis: 43 (16%) Male factor: 121 (44%) Tubal factor: 45 (16%) PCOS: 14 (5%) Other: 10 (4%) 2 causes: 27 (10%) Inclusion criteria: Aged <38 years, with a body mass index (BMI) <28 kg/m^2^, who had four or more follicles of an expected size >18 mm at the time of hCG injection, and who had undergone no more than three IVF treatments previously, were accepted for the study. Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain by VAS | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: +
Stener-Victorin, Waldenstrom, Wikland, et al., 2003 #16350 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain by VAS | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: +
Stener-Victorin, Waldenstrom, Wikland, et al., 2003 #16350 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain by VAS | EA and PCB | 43 | 93 | 136 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: +
Stener-Victorin, Waldenstrom, Wikland, et al., 2003 #16350 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain by VAS | Alfentanil and PCB | 49 | 89 | 138 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: +
Stener-Victorin, Waldenstrom, Wikland, et al., 2003 #16350 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain by VAS | Total | 92 | 182 | 274 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: +
Stener-Victorin, Waldenstrom, Wikland, et al., 2003 #16350 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain by VAS | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: +
Stener-Victorin, Waldenstrom, Wikland, et al., 2003 #16350 | | | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain by VAS | Rel risk | 0.89 | 0.64 | 1.24 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%:+ Adequacy of randomization concealment: +
2) No difference in pain by VAS
Stephenson and Fluker, 2000 #6430 | Geographical location: Vancouver, Canada Study dates: March 1995–July 1998 Size of population (no. of patients): 51 Number of cycles analyzed: 51 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - COH with GnRH agonist, gonadotropins; - Randomized to placebo or intravenous immunoglobulin infusion (500 mg/kg over 4–6 hours) within 72 hours preceding embryo transfer, repeated 4 weeks later if + FHR | Age: Mean (SD): 36 Range: 28–44 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - At least 2 previous failed transfers, with at least 2 good quality embryos/transfer; Exclusion criteria:; - Age <18 or >44 years; - IgA deficiency; - Immunoglobulin hypersensitivity; - + serology for hepatitis B, C, HIV, HTLV | Definition(s) of outcome(s): Pregnancy: Positive fetal heart rate Live birth: Yes Multiples: NR Complications: NR | 1) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Stephenson and Fluker, 2000 #6430 | | | Definition(s) of outcome(s): Pregnancy: Positive fetal heart rate Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Stephenson and Fluker, 2000 #6430 | | | Definition(s) of outcome(s): Pregnancy: Positive fetal heart rate Live birth: Yes Multiples: NR Complications: NR | Study drug | 4 | 22 | 26 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Stephenson and Fluker, 2000 #6430 | | | Definition(s) of outcome(s): Pregnancy: Positive fetal heart rate Live birth: Yes Multiples: NR Complications: NR | Control | 3 | 22 | 25 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Stephenson and Fluker, 2000 #6430 | | | Definition(s) of outcome(s): Pregnancy: Positive fetal heart rate Live birth: Yes Multiples: NR Complications: NR | | 7 | 44 | 51 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Stephenson and Fluker, 2000 #6430 | | | Definition(s) of outcome(s): Pregnancy: Positive fetal heart rate Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.28 | 0.32 | 5.16
Stern, Chamley, Norris, et al., 2003 #15940 | Geographical location: Victoria, Australia & Epsom, New Zealand Study dates: 1994–1997 Size of population (no. of patients): 143 Number of cycles analyzed: 300 Number of cycles per patient: 2.1 Study type: RCT Interventions; - Beginning on day of embryo transfer through hCG results, randomized to self-administered; (a) heparin 5000 U sc twice daily plus 100 mg aspirin daily, or; (b) placebo heparin and aspirin; - monitored with aPTT and platelet counts; - if no pregnancy, treatment alternated in subsequent cycle | Age: Mean (SD): 35.2 (4.6%) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 44 (30%) Endometriosis: 11 (8%) Male factor: 41 (29%) Tubal factor: 33 (23%) PCOS: 6 (4%) Inclusion criteria:; - Women seropositive for at least one antiphospholipid (APA), antinuclear (ANA), or beta 2 glycoprotein I autoantibody,; - >10 embryos transferred without achieving pregnancy; Exclusion criteria:; - abnormal findings on hysteroscopic evaluation of the uterine cavity; - osteoporosis,; - known hematological/thrombotic disorders including thrombophilia, platelet dysfunction, or previous thrombosis | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | 1) Live birth rate (1^st^ cycle only): | | | | Comments: Crossover design makes it impossible to calculate cumulative per patient pregnancy rate Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Stern, Chamley, Norris, et al., 2003 #15940 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg -
Stern, Chamley, Norris, et al., 2003 #15940 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | Heparin/aspirin | 11 | 63 | 74
Stern, Chamley, Norris, et al., 2003 #15940 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | Control | 10 | 59 | 69
Stern, Chamley, Norris, et al., 2003 #15940 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | | 21 | 122 | 143
Stern, Chamley, Norris, et al., 2003 #15940 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI
Stern, Chamley, Norris, et al., 2003 #15940 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | Rel risk | 1.03 | 0.46 | 2.26
2) Results similar for analysis on per-cycle basis
Strehler, Abt, El-Danasouri, et al., 2001 #58550 | Geographical location: Ulm, Germany Study dates: Jan 1998–June 1999 Size of population (no. of patients): 578 Number of cycles analyzed: 578 Number of cycles per patient: 1.0 Study type: RCT Interventions: Long protocol GnRH agonist downregulation, randomized to stimulation with; (a) hMG vs; (b) rFSH | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 36 (5%) Endometriosis: 21 (3%) Male factor: 462 (80%) Tubal factor: 137 (24%) Non-mutually exclusive categories Inclusion criteria:; - Scheduled for IVF/ICSI; - Age ≤ 40; - ≤ 4 previous attempts; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 6 weeks Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy (per randomized subject): | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Strehler, Abt, El-Danasouri, et al., 2001 #58550 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 6 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg- | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Strehler, Abt, El-Danasouri, et al., 2001 #58550 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 6 weeks Live birth: NR Multiples: NR Complications: NR | rFSH | 78 | 218 | 296 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Strehler, Abt, El-Danasouri, et al., 2001 #58550 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 6 weeks Live birth: NR Multiples: NR Complications: NR | hMG | 80 | 202 | 282 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Strehler, Abt, El-Danasouri, et al., 2001 #58550 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 6 weeks Live birth: NR Multiples: NR Complications: NR | Total | 158 | 420 | 578 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Strehler, Abt, El-Danasouri, et al., 2001 #58550 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac on ultrasound at 6 weeks Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.93 | 0.71 | 1.21
Surrey, Silverberg, Surrey, et al., 2002 #58560 | Geographical location: Englewood, CA; Austin, TX; Beverly Hills, CA Study dates: NR Size of population (no. of patients): 51 Number of cycles analyzed: 51 Number of cycles per patient: 1.0 Study type: RCT Interventions: Endometriosis, scheduled for IVF/ET, randomized to (a) 3 months GnRH agonist (leuprolide) vs.(b) no treatment | Age: Mean (SD): Agonist: 33.1 (0.7) No treatment: 32.6 (0.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Endometriosis: 100% Inclusion criteria:; - Infertile patients with endometriosis documented at laparoscopy or laparotomy within 60 months of cycle initiation (range, 2–55 months); - Regular menses (every 26–33 days); - Candidates for autologous IVF-ET undergoing fresh embryo transfer only; Exclusion criteria:; - GnRH agonist in previous 12 months; - FSH > 12; - Ovarian endometrioma | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR on ultrasound Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: Not clear if randomization stratified by center Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Surrey, Silverberg, Surrey, et al., 2002 #58560 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR on ultrasound Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: Not clear if randomization stratified by center Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Surrey, Silverberg, Surrey, et al., 2002 #58560 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR on ultrasound Live birth: NR Multiples: NR Complications: NR | GnRH | 20 | 5 | 25 | Comments: Not clear if randomization stratified by center Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Surrey, Silverberg, Surrey, et al., 2002 #58560 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR on ultrasound Live birth: NR Multiples: NR Complications: NR | No Rx | 14 | 12 | 26 | Comments: Not clear if randomization stratified by center Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Surrey, Silverberg, Surrey, et al., 2002 #58560 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR on ultrasound Live birth: NR Multiples: NR Complications: NR | Total | 34 | 17 | 51 | Comments: Not clear if randomization stratified by center Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Surrey, Silverberg, Surrey, et al., 2002 #58560 | | | Definition(s) of outcome(s): Pregnancy: Gestational sac with FHR on ultrasound Live birth: NR Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: Not clear if randomization stratified by center Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 1.49 | 0.99 | 2.23
Tang, Glanville, Orsi, et al., 2006 #56080 | Geographical location: Leeds, UK Study dates: 2001–2004 Size of population (no. of patients): 101 Number of cycles analyzed: 101 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - Long GnRH agonist protocol; - Randomized to; (a) metformin 850 mg or; (b) placebo BID from first day of down-regulation until egg retrieval | Age: Mean (SD): metformin 31.3, placebo 31.1 Race/ethnicity (n [%]): NR Diagnoses (n [%]): PCOS: 100% Inclusion criteria:; - PCOS, normal FSH; - ages 20–39; - Undergoing IVF/ICSI; Exclusion criteria:; - concurrent hormone therapy within the previous 6 weeks; - any chronic disease that could interfere with the absorption, distribution, metabolism or excretion of metformin; - renal or liver disease.; - significant systemic disease or diabetes (type 1 or 2) | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy > 12 weeks Live birth: > 24 weeks Multiples: NR Complications: Side effects, severe OHSS (symptomatic, or embryos frozen because considered high risk) | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | Study drug | 17 | 35 | 52 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | Control | 8 | 41 | 49 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | | 25 | 76 | 101 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | Rel risk | 2.00 | 0.95 | 4.21 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | Metformin | 17 | 35 | 52 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | Placebo | 6 | 43 | 49 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | | 23 | 78 | 101 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | Rel risk | 2.67 | 1.15 | 6.22 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | 3) Severe OHSS: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | Metformin | 2 | 50 | 52 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | Placebo | 10 | 39 | 49 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | | 12 | 89 | 101 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | Rel risk | 0.19 | 0.04 | 0.82 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | 4) Side effects: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | Study drug | 23 | 29 | 52 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | Control | 1 | 41 | 42 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | | 24 | 70 | 94 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Tang, Glanville, Orsi, et al., 2006 #56080 | | | | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization +concealment:
Rel risk | 18.58 | 2.62 | 131.94
Tang, Ng, So, et al., 2001 #3720 | Geographical location: Hong Kong, China Study dates: 9/1999 – 10/2000 Size of population: 800 Number of cycles analyzed: 800 Number of cycles per patient: 1.00 Study type: RCT Interventions: Ultrasound-guided ET vs. Clinical touch method | Age: Mean (SD):34.3 (3.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility:79(9.9) Endometriosis: 60(7.5) Male factor: 354(44.3) Tubal factor: n/a PCOS: n/a Other (specify): Tuboperitoneal: 228(28.5) Mixed 51(6.4) Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Clinical pregnancy: Positive uhCG and +gestational sac on u/s, irrespective of whether it was intra- or extrauterine, by u/s examination Ongoing pregnancy: +FCA at 10 wks gestation Live birth: NR Multiples: Yes Complications: NR | 1) Clinical pregnancy: | | | | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | | Out + | Out - | Total | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | u/s guided | 104 | 296 | 400 | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | clinical touch | 90 | 310 | 400 | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | Total | 194 | 606 | 800 | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | Rel risk | 1.16 | 0.90 | 1.48 | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | 2) Ongoing pregnancy: | | | | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | | Out + | Out - | Total | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | u/s guided | 94 | 306 | 400 | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | clinical touch | 76 | 324 | 400 | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | Total | 170 | 630 | 800 | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | Rel risk | 1.24 | 0.95 | 1.62 | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | 3) Multiple pregnancy: | | | | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | | Out + | Out - | Total | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | u/s guided | 31 | 73 | 104 | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | clinical touch | 20 | 70 | 90 | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | Total | 51 | 143 | 194 | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tang, Ng, So, et al., 2001 #3720 | | | | | Value | Lower 95% CI | Upper 95% CI | Comments: Powered to detect 8% absolute difference in pregnancy rates Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.34 | 0.82 | 2.18
Tarlatzis, Tavmergen, Szamatowicz, et al., 2006 #58570 | Geographical location: 6 centers in Greece, Israel, Poland, Turkey Study dates: NR Size of population (no. of patients): 114 Number of cycles analyzed: 114 Number of cycles per patient: 1.0 Study type: RCT Interventions: Down-regulation with GnRH agonist, rFSH until lead follicle 14 mm, then randomized to; (a) rFSH + placebo; (b) rFSH + rLH up to 10 days prior to ooycte retrieval | Age: Mean (SD): FSH only: 30.3 (3.6) FSH + LH: 30.5 (3.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 64 (56%) Tubal factor: 41 (36%) Other: 9 (8%) Inclusion criteria:; - Age 18–37; - Normal uterus and two ovaries; - Scheduled to undergo controlled ovarian stimulation prior to IVF with ICSI; - Normal ovulatory cycles of 24–35 days; - Maximum FSH and prolactin concentrations of 12 IU/l and 1040 mIU/l, respectively, during early follicular phase (days 2–6); - No evidence of other gynecological pathology (except tubal) based on ultrasonography and laboratory investigations; Exclusion criteria: Previous cycle with < 2 oocytes retrieved | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 35 days after retrieval Live birth: Yes Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tarlatzis, Tavmergen, Szamatowicz, et al., 2006 #58570 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 35 days after retrieval Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tarlatzis, Tavmergen, Szamatowicz, et al., 2006 #58570 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 35 days after retrieval Live birth: Yes Multiples: NR Complications: NR | FSH + LH | 9 | 46 | 55 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tarlatzis, Tavmergen, Szamatowicz, et al., 2006 #58570 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 35 days after retrieval Live birth: Yes Multiples: NR Complications: NR | FSH | 14 | 45 | 59 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tarlatzis, Tavmergen, Szamatowicz, et al., 2006 #58570 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 35 days after retrieval Live birth: Yes Multiples: NR Complications: NR | Total | 23 | 91 | 114 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tarlatzis, Tavmergen, Szamatowicz, et al., 2006 #58570 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 35 days after retrieval Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tarlatzis, Tavmergen, Szamatowicz, et al., 2006 #58570 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 35 days after retrieval Live birth: Yes Multiples: NR Complications: NR | Rel risk | 0.69 | 0.32 | 1.46 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tarlatzis, Tavmergen, Szamatowicz, et al., 2006 #58570 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 35 days after retrieval Live birth: Yes Multiples: NR Complications: NR | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tarlatzis, Tavmergen, Szamatowicz, et al., 2006 #58570 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 35 days after retrieval Live birth: Yes Multiples: NR Complications: NR | | Live birth + | Live birth - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tarlatzis, Tavmergen, Szamatowicz, et al., 2006 #58570 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 35 days after retrieval Live birth: Yes Multiples: NR Complications: NR | FSH + LH | 6 | 49 | 55 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tarlatzis, Tavmergen, Szamatowicz, et al., 2006 #58570 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 35 days after retrieval Live birth: Yes Multiples: NR Complications: NR | FSH | 10 | 49 | 59 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tarlatzis, Tavmergen, Szamatowicz, et al., 2006 #58570 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 35 days after retrieval Live birth: Yes Multiples: NR Complications: NR | Total | 16 | 98 | 114 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tarlatzis, Tavmergen, Szamatowicz, et al., 2006 #58570 | | | Definition(s) of outcome(s): Pregnancy: FHR on ultrasound 35 days after retrieval Live birth: Yes Multiples: NR Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.64 | 0.25 | 1.65
Tay and Lenton, 2003 #15090 | Geographical location: Sheffield, UK Study dates: Jan 1998–Jan 1999 Size of population (no. of patients): 63 Number of cycles analyzed: 63 Number of cycles per patient: 1.0 Study type: RCT Interventions: GnRH agonist COH; randomized to; (a) progesterone 200 mg BID vaginally vs; (b) Progesterone + 2mg E2 valerate daily | Age: Mean (SD): 32.2 (4.5) Range: 22–39 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - No previous infertility treatment; - Infertility at least 2 years; Exclusion criteria: Basal FSH >10 | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | 1) Clinical pregnancy: | | | | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Tay and Lenton, 2003 #15090 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Tay and Lenton, 2003 #15090 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | Study drug | 5 | 28 | 33 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Tay and Lenton, 2003 #15090 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | Control | 7 | 28 | 35 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Tay and Lenton, 2003 #15090 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | | 12 | 56 | 68 | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Tay and Lenton, 2003 #15090 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: - Adequacy of randomization concealment: -
Rel risk | 0.76 | 0.27 | 2.15
Tay and Lenton, 2005 #40970 | Geographical location: Sheffield, UK Study dates: NR Size of population (no. of patients): 168 Number of cycles analyzed: 168 Number of cycles per patient: 1.0 Study type: RCT Interventions:; (a) micronized progesterone 200 mg rectally twice daily, from day 4 post retrieval for 14 days; (b) micronized progesterone 8% gel once daily from day 4 post retrieval for 14 days; (c) micronized progesterone capsules, varying dosage, from day 4 post retrieval for 14 days; (d) 1500 IU hCG days 4 and 7 | Age: Mean (SD): Overall mean 32.4 Range: 21–41 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - BMI 19–20; - Day 3 FSH <12; Exclusion criteria: Pre-ovulatory E2 >15,000 pmol/L and/or >15 follicles | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | 1) Ongoing pregnancy, rectal progesterone vs progesterone capsules: | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | Rectal | 12 | 35 | 47 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | Capsule | 19 | 55 | 74 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | | 31 | 90 | 121 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | Rel risk | 0.99 | 0.53 | 1.85 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy, progesterone gel vs progesterone capsules: | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | Gel | 13 | 36 | 49 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | Capsule | 19 | 55 | 74 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | | 32 | 91 | 123 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.03 | 0.56 | 1.89 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | 3) Ongoing pregnancy, hCG vs progesterone capsules: | | | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | hCG | 12 | 35 | 47 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | Capsule | 19 | 55 | 74 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | | 31 | 90 | 121 | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Tay and Lenton, 2005 #40970 | | | Definition(s) of outcome(s): Pregnancy: Ongoing pregnancy—greater than 14 weeks Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: No adjustment for multiple comparisons Quality assessment: Randomization method: - Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: -
Rel risk | 0.99 | 0.53 | 1.85
Tesarik, Hazout, and Mendoza, 2005 #41280 | Geographical location: Granada, Spain and Paris, France Study dates: NR Size of population (no. of patients): 100 Number of cycles analyzed: 100 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - Long GnRH agonist protocol with rFSH; - On day 7 of ovarian stimulation, randomized to (a) 8 IU growth hormone or (b) placebo until day after ovulation triggering dose of hCG | Age: Mean (SD): GH: 42.2 (1.1), placebo 42.3 (1.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Women aged 41–44; Exclusion criteria:; - day 3 serum FSH >14 IU/l; - day 3 inhibin B <30 pg/ml. | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | 1) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, and Mendoza, 2005 #41280 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, and Mendoza, 2005 #41280 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | GH | 11 | 39 | 50 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, and Mendoza, 2005 #41280 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | Placebo | 2 | 48 | 50 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, and Mendoza, 2005 #41280 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | | 13 | 87 | 100 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, and Mendoza, 2005 #41280 | | | Definition(s) of outcome(s): Pregnancy: NR Live birth: Yes Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 5.50 | 1.28 | 23.56
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | Geographical location: Granada, Spain Study dates: Sep 2003–Sep 2005 Size of population (no. of patients): 600 Number of cycles analyzed: 600 Number of cycles per patient: 1.0 Study type: RCT Interventions: 300 GnRH agonist, 300 GnRH antagonist COH Randomized to (a) placebo, or (b) single dose GnRH agonist 3 days after embryo transfer All received E2 + progesterone for luteal support | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 1) Ongoing pregnancy, GnRH agonist downregulation: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | GnRH a | 66 | 84 | 150 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Placebo | 54 | 96 | 150 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 120 | 180 | 300 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.22 | 0.92 | 1.62 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 2) Ongoing pregnancy, GnRH antagonist down regulation: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | GnRH a | 65 | 85 | 150 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Placebo | 46 | 104 | 150 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 111 | 189 | 300 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Rel risk | 1.41 | 1.04 | 1.91 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | 3) Ongoing pregnancy, both groups combined: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | GnRHa | 131 | 169 | 300 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | Placebo | 110 | 190 | 300 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | 241 | 359 | 600 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Tesarik, Hazout, Mendoza-Tesarik, et al., 2006 #56160 | | Age: Mean (SD): Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI Exclusion criteria:; - Age > 40; - Need for testicular sperm extraction | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.19 | 0.98 | 1.45
Thompson, Murray, MacLennan, et al., 2000 #58580 | Geographical location: Aberdeen, UK Study dates: NR Size of population (no. of patients): 112 Number of cycles analyzed: 112 Number of cycles per patient: 1.0 Study type: RCT Interventions: Randomized to inhalational (isodex) or IV (fentanyl/midazolam) analgesia for oocyte retrieval | Age: Mean (SD): Inhalational: 33.9 (4.0) IV: 32 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Scheduled for oocyte retrieval for IVF/ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Thompson, Murray, MacLennan, et al., 2000 #58580 | | Age: Mean (SD): Inhalational: 33.9 (4.0) IV: 32 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Scheduled for oocyte retrieval for IVF/ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Thompson, Murray, MacLennan, et al., 2000 #58580 | | Age: Mean (SD): Inhalational: 33.9 (4.0) IV: 32 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Scheduled for oocyte retrieval for IVF/ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | IV | 7 | 48 | 55 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Thompson, Murray, MacLennan, et al., 2000 #58580 | | Age: Mean (SD): Inhalational: 33.9 (4.0) IV: 32 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Scheduled for oocyte retrieval for IVF/ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | Inhalational | 10 | 47 | 57 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Thompson, Murray, MacLennan, et al., 2000 #58580 | | Age: Mean (SD): Inhalational: 33.9 (4.0) IV: 32 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Scheduled for oocyte retrieval for IVF/ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | Total | 17 | 95 | 112 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Thompson, Murray, MacLennan, et al., 2000 #58580 | | Age: Mean (SD): Inhalational: 33.9 (4.0) IV: 32 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Scheduled for oocyte retrieval for IVF/ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Thompson, Murray, MacLennan, et al., 2000 #58580 | | Age: Mean (SD): Inhalational: 33.9 (4.0) IV: 32 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Scheduled for oocyte retrieval for IVF/ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Not defined Live birth: NR Multiples: NR Complications: Pain | Rel risk | 0.73 | 0.30 | 1.77 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
2) Pain scores worse for inhalation; no significant difference in satisfaction
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | Geographical location: Göteborg and Linköping, Sweden; Copenhagen, Denmark; Haugesund Norway. Study dates: May 2000 to Oct 2003 Size of population (no. of patients): 661 Number of cycles analyzed: 661 Number of cycles per patient: 1.0 Study type: RCT Interventions: SET: Transfer of a single fresh embryo and, if there was no live birth, subsequent transfer of a single frozen-and-thawed embryo DET: Single transfer of two fresh embryos | Age: Mean (SD): 30.8 (3.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Endometriosis: 96 Male factor: 319 Tubal factor: 130 Other: Hormonal: 144 Unknown: 126 (More than one diagnosis per couple was possible; 513 couples had one, 140 had two, and 8 had three diagnoses.) Inclusion criteria: < 36 years of age, were undergoing their first or second in vitro fertilization cycle, and had at least two embryos of good quality available for transfer or freezing. [The original protocol stipulated that the patient had to be less than 35 years of age and have at least three good-quality embryos available, but these criteria were modified in an amendment after the first 215 patients were enrolled, owing to a change in usual clinical practice in Sweden.] Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | | Preg + | Preg - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | SET | 9 | 321 | 330 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | DET | 16 | 315 | 331 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | Total | 25 | 636 | 661 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 0.56 | 0.25 | 1.26 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | 2) Live birth: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | | Live birth + | Live birth - | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | SET | 158 | 172 | 330 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | DET | 174 | 157 | 331 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | Total | 332 | 329 | 661 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | Rel risk | 0.91 | 0.78 | 1.06 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | 3) Multiple births: | | | | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | | Multiple + | Multiple- | Total | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | SET | 1 | 127 | 128 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | DET | 47 | 95 | 142 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | Total | 48 | 222 | 270 | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Thurin, Hausken, Hillensjo, et al., 2004 #10520 | | | Definition(s) of outcome(s): Pregnancy: Positive test for urinary HCG (> 20 IU/L) or serum HCG ≥2 IU 2 weeks after transfer Live birth: Yes Multiples: Yes Complications: NR | | Value | Lower 95% CI | Upper 95% CI | Comments: None Quality assessment: Randomization method: + Blinding: + Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 0.02 | 0.00 | 0.17
Tremellen, Valbuena, Landeras, et al., 2000 #6470 | Geographical location: Adelaide, Australia, and Madrid and Murcia, Spain Study dates: June 1996–Dec 1998 Size of population (no. of patients): 478 Number of cycles analyzed: 478 Number of cycles per patient: 1.0 Study type: RCT Interventions:; - Austraila: randomized to (a) intercourse at least once in the 4 day period 2 days before and 2 days after embryo transfer, or (b) abstaining; - Spain: (a) intercourse at least twice, 12 hours before and 12 hours after embryo transfer, or (b) abstain during entire IVF cycle | Age: Mean (SD): 33 (pooled) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 17% Male factor: 47% Other: “Female factor” 20% Combined: 15% Inclusion criteria:; - 18–40; - stable relationship; Exclusion criteria:; - donor eggs/sperm; - Hepatitis B, C, HIV | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | 1) Pregnancy: | | | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Tremellen, Valbuena, Landeras, et al., 2000 #6470 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | | Preg + | Preg - | | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Tremellen, Valbuena, Landeras, et al., 2000 #6470 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | Intercourse | 47 | 195 | 242 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Tremellen, Valbuena, Landeras, et al., 2000 #6470 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | Control | 39 | 197 | 236 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Tremellen, Valbuena, Landeras, et al., 2000 #6470 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | | 86 | 392 | 478 | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Tremellen, Valbuena, Landeras, et al., 2000 #6470 | | | Definition(s) of outcome(s): Pregnancy: +FHR Live birth: NR Multiples: NR Complications: NR | | | Lower 95% CI | Upper 95 % CI | Comments: None Quality assessment: Randomization method: + Blinding: - Dropout rate < 20%: + Adequacy of randomization concealment: +
Rel risk | 1.18 | 0.80 | 1.73

Evidence Table 3. Question 4 - Longer-Term Outcomes

Study | Study Design | Patients | Clinical Presentation | Results | | | | Comments/Quality Scoring
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | Geographical location: Cairo, Egypt Study dates: Jan 1997 – Dec 1999 Size of population: 430 consecutive babies conceived by ICSI from 320 deliveries (220 singletons, 198 twins, 12 triplets), 430 babies conceived naturally from 418 deliveries (406 singletons, 12 twins) Study type: Cohort Prospective cohort of consecutive ICSI deliveries, compared to control grp of consecutive naturally-conceived pregnancies. Planned sample size had 80% power to detect 2.5% difference in chromosomal anomalies with 2-sided significance level of 0.05 | Age: Mean (SD): ICSI 30 (5.2) Ctrl 28.5 (4.1) Range: ICSI 17–41 Ctrl 18–39 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women who conceived through ICSi in this center who were observed by OB of this center and delivered at this hospital; consecutive deliveries. Exclusion criteria: Observed by another obstetrician | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | 6 sex chromosome anomalies | | | | Comments:; - Significant consanguinity in both grps (9.7% ICSI, 11% ctrl), but similar.; - Similar mat & pat ages in both grps.; - Only 6/15 parents of infants with abnl karyotypes underwent karyotyping themselves; unclear whether these are de novo mutations or inherited.; - 2/6 had abnl paternal karyotype; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | 8 autosomal anomalies
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | 1 combined
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | 1) Abnl karyotypes:
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | | Abnl karyo | Nl karyo | Total
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | ICSI | 15 | 415 | 430
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | Natural | 0.5 | 430 | 430.5
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | Total | 15.5 | 845 | 860.5
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | | Value | Lower 95% CI | Upper 95% CI
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | Rel risk | 30.03 | 1.80 | 501.13
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | 2) Abnl kayotype by method of sperm collection (ejaculated vs surgically retrieved):
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | | Abnl karyo | Nl karyo | Total
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | ICSI - ejac | 14 | 374 | 388
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | ICSI - surg | 1 | 41 | 42
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | Total | 15 | 415 | 430
Aboulghar, Aboulghar, Mansour, et al., 2001 #4560 | | | Definition(s) of outcome(s): Karyotype performed on cord blood or peripheral blood. | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.52 | 0.20 | 11.24
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries ≥ 24 weeks, divided by ART, ovulation induction, or spontaneous Exclusion criteria:; - Vanishing twins (n = 32); - Only 1 pregnancy used for 83 mothers with > 1 twin pregnancy (randomly selected) | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | 1) Small for gestational age, IVF vs. spontaneous: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | | SGA + | SGA - | Total
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | IVF | 93 | 465 | 558
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | Spont | 794 | 2900 | 3694
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | Total | 887 | 3365 | 4252
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | | Value | Lower 95% CI | Upper 95% CI
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | Rel risk | 0.78 | 0.64 | 0.94
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | 2) Small for gestational age, ovulation induction vs. spontaneous:
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | | SGA + | SGA - | Total
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | Ov Ind | 102 | 376 | 478
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | Spont | 794 | 2900 | 3694
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | Total | 896 | 3276 | 4172
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | | Value | Lower 95% CI | Upper 95% CI
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | Rel risk | 0.99 | 0.83 | 1.19
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | 3) Malformation, IVF vs. spontaneous:
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | | Mal + | Mal - | Total
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | IVF | 24 | 454 | 478
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | Spont | 274 | 3420 | 3694
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | Total | 298 | 3874 | 4172
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | | Value | Lower 95% CI | Upper 95% CI
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | Rel risk | 0.68 | 0.45 | 1.02
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | 4) Malformation, ovulation induction vs. spontaneous:
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | | Mal + | Mal - | Total
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | Ov ind | 67 | 491 | 558
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | Spont | 274 | 3420 | 3694
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | Total | 341 | 3911 | 4252
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | | Value | Lower 95% CI | Upper 95% CI
Adler-Levy, Lunenfeld, and Levy, 2007 #70280 | Geographical location: Beer Sheva, Israel Study dates: Jan 1988–Dec 2002 Size of population (no. of patients): 4730 Study type: Cohort | | Definition(s) of outcome(s): Diabetes Pregnancy induced hypertension Preterm delivery Birthweight Malformations | Rel risk | 1.62 | 1.26 | 2.08
5) After adjustment for maternal age and nulliparity:; - Increased risk for gest diabetes in both groups (IVF 2.41, 95% CI 1.77–3.29; induction 1.71, 95% CI 1.20–2.42); - Lower risk for preterm birth for IVF (0.91, 95% CI 0.88–0.94) but not induction (1.01, 95% CI 0.97–1.35); - Lower risk for malformations with induction (0.60, 95% CI 0.38–0.95)
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | Age: Mean (SD): ICSI 33.8 (5.7), ctrl 33.7 (5.6) Race/ethnicity (n [%]): ICSI 85% Chinese, 10% Malay, 5% Indian Ctrls 83% Chinese, 13% Malay, 4% indian Diagnoses (n [%]): NR Inclusion criteria: Eligible subjects identified retrospectively; liveborns conceived by ICSI, invited by mail & phone call. Controls naturally conceived during same study period, randomly selected using hospital database, matched for maternal age, sex, del date, race, plurality, parity. 3:1 controls: ICSI Exclusion criteria: No consent given, ectopic or early miscarriage, neonatal death | Definition(s) of outcome(s): Major malformation = resulted in functional impairment or required surgical correction BSID = Bayley Scale of Development II; - MDI = mental developmental index; - PDI = psychomotor developmental index; - Mean scores for both 100; VABS = Vineland Adaptive Behaviour Scale Mean score 100 Exam at 2yo | 1) C/S in singletons | | | | Comments:; - 10% study pts & 3% ctrls declined to participate; - ICSI grp had higher income, but no signif diff in level of education; - Small numbers; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: + Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | | CS+ | CS- | Total
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | ICSI | 19 | 22 | 41
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | Ctrl | 60 | 125 | 185
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | Total | 79 | 147 | 226
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | Rel risk | 1.43 | 0.97 | 2.11
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | 2) Bayley MDI >115 (>2SD above mean):
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | | MDI > 115 | MDI ≤ 115 | Total
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | ICSI | 6 | 70 | 76
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | Ctrl | 6 | 255 | 261
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | Total | 12 | 325 | 337
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | Rel risk | 3.43 | 1.14 | 10.34
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | Other developmental outcomes presented as continuous variables; no diff in any by whole grp, singletons, multiples, EXCEPT mean Bayley MDI for multiples higher in ICSI grp (92 vs. 86, p=0.03). Difference NS (and all others NS) when adjusted for maternal education, income, housing type, plurality, gestational age, presence of congenital malformation
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | 3) Major malformations:
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | | Malf+ | Malf- | Total
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | ICSI | 6 | 70 | 76
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | Ctrl | 7 | 254 | 261
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | Total | 13 | 324 | 337
Agarwal, Loh, Lim, et al., 2005 #40680 | Geographical location: Singapore Study dates: Aug 1998 – 1999 Size of population: 76 ICSI, 261 naturally conceived Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 2.94 | 1.02 | 8.50
Alikani, Ceklenial, Walters, et al., 2003 #15800 | Geographical location: West Orange, NJ Study dates: 7 yr period (dates NR) Size of population: 4,305 cycles 81 cycles involved monozygotic (MZ) fetuses Study type: Case-control | Age: Mean (SD): MZ twin preg - 35.3 (0.49) Non-MZ twins - 34.5 (0.09) Singletons - 35.5 (0.09) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF pts with confirmed pregnancy at 6 wks Exclusion criteria: Extra sacs w/o evidence of embryo development | Definition(s) of outcome(s): Incidence of MZ twinning | Overall incidence of MZ twinning 1.88% No sig diff (MZ versus non-MZ twins or singletons) in mat or pat age, # drug ampoules, # days gonadotropins, Peak E2, peak P, # oocytes retrieved, # embryos replaced. No categorical variables to analyze by 2×2 tables. Of 81 MZ twin pregnancies, 40 fetuses were selectively reduced. | | | | Comments: Major strength is early ascertainment of cases through routine US at 6 wks (allows for inclusion of those MZ pregnancies that were later reduced) Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | Age: Mean (SD): IVF 33.3, ctrl 29.7 Race/ethnicity (n [%]): IVF 78.2% Dutch, Ctrl 78.6% Dutch Diagnoses (n [%]): NR Inclusion criteria: 3 national registries: National Perinatal Database for Primary Care (midwife births), National Perinatal Database for Secondary Care (OB births), National Neonatology Database (records admissions within 28d of life, and readmissions for neonatal problems). Reviewed for IVF coded as conception method. Exclusion criteria: Pregnancies <16wks not included in National Perinatal Databases. | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | 1) Overall congenital malformations: | | | | Comments:; - Complete information from 85% of all Dutch births.; - Includes pregnancies with gestational age of at least 16 wks.; - Would not include terminations before then.; - Same data source of malformations for both grps, not general population statistics.; - However, only includes admissions within 28d, so would miss dx made as output or made after that time period.; - No mention of terminations.; - No distinction for ICSI kids.; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: - Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | | Malf + | Malf - | Total
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | IVF | 137 | 4087 | 4224
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | Nat | 8526 | 306079 | 314605
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | Total | 8663 | 310166 | 318829
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | | Value | Lower 95% CI | Upper 95% CI
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | Odds rat | 1.20 | 1.01 | 1.43
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | When adjusted for confounders (mat age, parity, ethnicity), OR for all malformations became insignificant (1.03, 0.86–1.23).
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | 2) Major malformations:
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | | Malf + | Malf - | Total
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | IVF | 28 | 4196 | 4224
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | Nat | 1700 | 312905 | 314605
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | Total | 1728 | 317101 | 318829
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | | Value | Lower 95% CI | Upper 95% CI
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | Odds rat | 1.23 | 0.84 | 1.79
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | 3) Minor malformations:
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | | Malf + | Malf - | Total
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | IVF | 54 | 4170 | 4224
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | Nat | 3445 | 311160 | 314605
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | Total | 3499 | 315330 | 318829
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | | Value | Lower 95% CI | Upper 95% CI
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | Odds rat | 1.17 | 0.89 | 1.53
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | Raw data not presented:
Anthony, Buitendijk, Dorrepaal, et al., 2002 #1350 | Geographical location: Nijmegen, Netherlands Study dates: 1995 - 1996 Size of population: 4,224 IVF children, 314,605 naturally-conceived children Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Congenital malformations. Coded by organ system. No definition given, either for congenital malformation or major/minor. | By specific organ system, only cardiovascular malformations significantly more common (OR 1.56 [1.10–2.22]) in IVF grp.
By specific malformation, SUA, inguinal hernia, club foot were more frequent in IVF grp. No adjustment for multiple comparisons though.
Bajoria, Ward, and Adegbite, 2006 #50370 | Geographical location: Manchester, UK Study dates: 1986-2000 Size of population (no. of patients): ART-only triplets N= 106 sets trichorionic-triamniotic triplets (TCTA) N= 34 sets dichorionic-triamniotic triplets (DCTA) Study type: Cohort | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | Definition(s) of outcome(s): Preterm birth < 30 wks Very low bwt < 1000 gm Respiratory distress syndrome (RDS) Anemia in neonate Intraventricular hemorrhage (IVH) Perinatal mortality = stillbirth + neonatal death | 1) PTB < 30wks by 2 triplet groups: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | | PTB+ | PTB- | Total
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | TCTA | 16 | 90 | 106
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | DCTA | 17 | 17 | 34
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | Total | 33 | 107 | 140
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | | Value | Lower 95% CI | Upper 95% CI
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | Rel risk | 0.30 | 0.17 | 0.53
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | 2) Very low birthweight by 2 triplet groups:
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | | vlbwt+ | vlbwt- | Total
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | TCTA | 34 | 284 | 318
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | DCTA | 43 | 59 | 102
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | Total | 77 | 343 | 420
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | | Value | Lower 95% CI | Upper 95% CI
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | Rel risk | 0.25 | 0.17 | 0.37
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | 3) RDS by 2 triplet groups:
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | | RDS+ | RDS- | Total
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | TCTA | 41 | 277 | 318
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | DCTA | 41 | 61 | 102
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | Total | 82 | 338 | 420
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | | Value | Lower 95% CI | Upper 95% CI
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | Rel risk | 0.32 | 0.22 | 0.46
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | 4) Anemia in neonate:
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | | anemia+ | anemia- | Total
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | TCTA | 5 | 313 | 318
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | DCTA | 20 | 82 | 102
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | Total | 25 | 395 | 420
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | | Value | Lower 95% CI | Upper 95% CI
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | Rel risk | 0.08 | 0.03 | 0.21
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | 5) Intraventricular hemorrhage:
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | | IVH+ | IVH- | Total
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | TCTA | 11 | 307 | 318
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | DCTA | 28 | 74 | 102
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | Total | 39 | 381 | 420
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | | Value | Lower 95% CI | Upper 95% CI
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | Rel risk | 0.13 | 0.07 | 0.24
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | 6) Perinatal mortality:
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | | perinatal mortality+ | perinatal mortality- | Total
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | TCTA | 23 | 295 | 318
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | DCTA | 40 | 62 | 102
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | Total | 63 | 357 | 420
Bajoria, Ward, and Adegbite, 2006 #50370 | | Age: DCTA 33yrs (25–41) TCTA 32yrs (19–43) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ART triplets Exclusion criteria: Spontaneous triplets Fetal reduction | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.18 | 0.12 | 0.29
Belva, Henriet, Liebaers, et al., 2007 #50590 | Geographical location: Brussels, Belgium Study dates: Children with 8^th^ birthday from Feb 2001–Dec 2003 Size of population (no. of patients): 150 ICSI 147 spontaneously conceived controls Study type: Cohort | Age: maternal age at birth Median: ICSI 32 (25–43); spontaneous: 30 (18–42) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - ICSI at institution for exposed, local schools for controls; - Born in appropriate time period; - singleton; - born at least 32 weeks of gestation.; Children with low birthweight or major malformations were not per se excluded from the study.; - Dutch-speaking; Exclusion criteria: NR | Definition(s) of outcome(s):; - Major malformations; - Minor malformations; - Pediatric hospitalizations; - NICU admissions; - Pregnancy complications (not specified); Variable response rate for specific variables—only malformation rates (complete denominator) reported here | 1) Major malformations: | | | | Comments:; - Only 61% of cohort participated—16% lost to follow-up, 23% refused participation; - Medical/neurologic/psychological assessment not blinded; - Self-reported history not validated against medical records; - No multivariate analysis (but numbers small—unlikely to have sufficient power); - Variable response rates for different outcomes within groups; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: - Analysis (multivariate adjustments) and reporting of results: -
Belva, Henriet, Liebaers, et al., 2007 #50590 | | | | | Out + | Out - | Total
Belva, Henriet, Liebaers, et al., 2007 #50590 | | | | Exp + | 15 | 135 | 150
Belva, Henriet, Liebaers, et al., 2007 #50590 | | | | Exp - | 5 | 142 | 147
Belva, Henriet, Liebaers, et al., 2007 #50590 | | | | Total | 20 | 277 | 297
Belva, Henriet, Liebaers, et al., 2007 #50590 | | | | | Value | Lower 95% CI | Upper 95% CI
Belva, Henriet, Liebaers, et al., 2007 #50590 | | | | Rel risk | 2.94 | 1.10 | 7.88
Belva, Henriet, Liebaers, et al., 2007 #50590 | | | | 2) Minor malformations:
Belva, Henriet, Liebaers, et al., 2007 #50590 | | | | | Out + | Out - | Total
Belva, Henriet, Liebaers, et al., 2007 #50590 | | | | Exp + | 35 | 115 | 150
Belva, Henriet, Liebaers, et al., 2007 #50590 | | | | Exp - | 25 | 127 | 152
Belva, Henriet, Liebaers, et al., 2007 #50590 | | | | Total | 60 | 242 | 302
Belva, Henriet, Liebaers, et al., 2007 #50590 | | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.42 | 0.89 | 2.25
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | 1) Anencephaly overall: | | | | Comments: Excluded those who continued pregnancy, either because they chose to or because of failed or late dx Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: - Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | | Anen+ | Anen- | Total
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | IVF | 1 | 12 | 13
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | Spont | 20 | 332 | 352
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | Total | 21 | 344 | 365
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | | Value | Lower 95% CI | Upper 95% CI
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | Odds rat | 1.38 | 0.17 | 11.18
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | 2) Anencephaly in twins:
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | | Anen+ | Anen- | Total
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | IVF | 1 | 7 | 8
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | Spont | 1 | 11 | 12
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | Total | 2 | 18 | 20
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | | Value | Lower 95% CI | Upper 95% CI
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | Odds rat | 1.57 | 0.08 | 29.41
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | 3) Anencephaly overall, ICSI vs spont:
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | | Anen+ | Anen- | Total
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | ICSI | 5 | 10 | 15
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | Spont | 20 | 332 | 352
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | Total | 25 | 342 | 367
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | | Value | Lower 95% CI | Upper 95% CI
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | Odds rat | 8.30 | 2.59 | 26.60
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | 4) Anencephaly in twins, ICSI vs spont:
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | | Anen+ | Anen- | Total
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | ICSI | 5 | 7 | 12
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | Spont | 1 | 11 | 12
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | Total | 6 | 18 | 24
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | | Value | Lower 95% CI | Upper 95% CI
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | Odds rat | 7.86 | 0.75 | 82.13
Ben-Ami, Vaknin, Reish, et al., 2005 #39230 | Geographical location: Tel Aviv, Israel Study dates: Jan 1997 – July 2004 Size of population: 380 Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women admitted during study period for termination of pregnancy bc of severe fetal anom Exclusion criteria: NR | Definition(s) of outcome(s): All twins dichorionic | No diff in IVF vs ICSI
Logistic regression used to determine influence of twinning or mode of conception, found correlation only between anencephaly and twinning.
Benshushan, Paltiel, Brzezinski, et al., 2001 #4380 | Geographical location: Jerusalem, Israel Study dates: Cases reported Jan 1989–Dec 1992 Size of population: 128 Study type: Case-control | Age: Mean at diagnosis (SD): Cases: 53.53 (6.37) Controls: 50.49 (7.82) Race/ethnicity (n [%]): European/American (cases 45.3%, ctrls 24.7%) Diagnoses (n [%]): NR Inclusion criteria:; - Histologically-confirmed diagnosis of endometrial CA; - First diagnosed and reported to Israel Cancer Registry 1989-92; - Born 1929-57 (because fertility drugs first used in Israel in 1960); - Living; Controls were randomly telephoned within same area codes as cases, same DOB range Exclusion criteria:; - Women who had undergone hysterectomy excluded as controls; - Had to contact women through their physicians - physicians obtained consent to interview patient | Definition(s) of outcome(s): Ascertainment of exposure to any infertility drug based on interview | 1) Use of any infertility drug: | | | | Comments:; - 21.6% potential cases had died before or during study period; - Of those living, interviewed only 39% (unable to locate pt or physician, illness, refusal by pt or physician) - non-response bias; - More cases European-American, hypertensive, obese; - Did not verify use of fertility drugs; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: - Appropriateness of the control population: + Verification that the control is free of cancer: - Comparability of cases and controls with respect to potential confounders: - Validated dietary assessment method: NR Appropriateness of statistical analyses: -
Benshushan, Paltiel, Brzezinski, et al., 2001 #4380 | Geographical location: Jerusalem, Israel Study dates: Cases reported Jan 1989–Dec 1992 Size of population: 128 Study type: Case-control | | Definition(s) of outcome(s): Ascertainment of exposure to any infertility drug based on interview | | Cases | Ctrls | Total
Benshushan, Paltiel, Brzezinski, et al., 2001 #4380 | Geographical location: Jerusalem, Israel Study dates: Cases reported Jan 1989–Dec 1992 Size of population: 128 Study type: Case-control | | Definition(s) of outcome(s): Ascertainment of exposure to any infertility drug based on interview | Infertility drug | 7 | 10 | 17
Benshushan, Paltiel, Brzezinski, et al., 2001 #4380 | Geographical location: Jerusalem, Israel Study dates: Cases reported Jan 1989–Dec 1992 Size of population: 128 Study type: Case-control | | Definition(s) of outcome(s): Ascertainment of exposure to any infertility drug based on interview | None | 121 | 245 | 366
Benshushan, Paltiel, Brzezinski, et al., 2001 #4380 | Geographical location: Jerusalem, Israel Study dates: Cases reported Jan 1989–Dec 1992 Size of population: 128 Study type: Case-control | | Definition(s) of outcome(s): Ascertainment of exposure to any infertility drug based on interview | Total | 128 | 255 | 383
Benshushan, Paltiel, Brzezinski, et al., 2001 #4380 | Geographical location: Jerusalem, Israel Study dates: Cases reported Jan 1989–Dec 1992 Size of population: 128 Study type: Case-control | | Definition(s) of outcome(s): Ascertainment of exposure to any infertility drug based on interview | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.42 | 0.53 | 3.81
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | Geographical location: Oss, Netherlands Study dates: NR (published 2002) Size of population: 340 pregnancies after ganireliex (a GnRH antagonist),, 134 after treatment with GnRH agonist Study type: Cohort Pooled results from 5 trials, 4 of which were RCTs | Age: Mean (SD): Ganirelix 31.4 (3.8), agonist 31.3 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Pregnancies ≥ 16wks from 5 clinical trials of ganirelix. Inclusion criteria not described in detail. Exclusion criteria: Pregnancies < 16wks, frozen embryo transfer (except for one trial in which frozen were allowed) | Definition(s) of outcome(s): Pregnancy info collected at trial site directly, or through questionnaire. Info about children collected at birth “and, optionally, until 8 wks after birth.” Congenital malformations classified by single person using 2 different definitions: Definition A: reduces viability or compromises quality of life and requires medical treatment. Def B: causes functional impairment or requires surgical intervention. | Btw 16–26wks, 8 losses in ganirelix grp (6 SAB, 2 selective/induced AB - one for cardiac malformation, one for meningomyelocele), 3 in agonist grp (all spont, unknown cause). | | | | Comments: Sponsored by Organon - Information collected at birth and optionally up to 8wks after birth Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: - Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | After 26wks, 5 IUFD's in ganirelix grp, 2 in agonist.
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | No major differences in rates of preterm birth, LBW, etc. Higher rates of preterm birth, VLBW, C/S with higher multiplicity in both grps.
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | 1) Any pregnancy complication:
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | | Preg complic + | Preg complic - | Total
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | Ganirelix | 159 | 181 | 340
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | Agonist | 69 | 65 | 134
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | Total | 228 | 246 | 474
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | | Value | Lower 95% CI | Upper 95% CI
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | Rel risk | 0.91 | 0.74 | 1.11
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | 2) Cesarean:
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | | C/S | Other | Total
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | Ganirelix | 147 | 184 | 331
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | Agonist | 59 | 73 | 132
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | Total | 206 | 257 | 463
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | | Value | Lower 95% CI | Upper 95% CI
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | Rel risk | 0.99 | 0.79 | 1.24
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | 3) Congenital malformations after 26 wks:
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | | Malf + | Malf - | Total
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | Ganirelix | 32 | 392 | 424
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | Agonist | 10 | 171 | 181
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | Total | 42 | 563 | 605
Boerrigter, de Bie, Mannaerts, et al., 2002 #1370 | | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.37 | 0.69 | 2.72
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | Geographical location: Brussels, Belgium; Göteborg, Sweden; and New York, NY Study dates: NR Size of population: 300 cases, 266 controls Study type: Consecutive intracytoplasmic sperm injection (ICSI) cases matched with spontaneous conception (SC) controls; medical records reviewed & exam at age 5 | Age: Mean (SD): 5.2 cases, 5.4 controls Range: 4.0–6.3 cases, 4.3–6.1 controls Race/ethnicity (n [%]): 100% Caucasian from 2 European sites; 4/102 cases and 7/55 controls from NY were “non-Caucasian” Diagnoses (n [%]): NR Inclusion criteria: Singletons born after ICSI (cases) or SC (controls). Cases consecutively recruited at age 5, controls matched for sex, age, maternal age. Exclusion criteria: Multiple birth, birth < 32 wk, maternal or child language different from national language. No donor sperm used. | Definition(s) of outcome(s): Chronic illness = disorder of ≥ 3 mos duration during the last yr that interfered with daily functioning and/or required treatment Neuro exam included tone, CN status, DTRs, walking, running, jumping Malformations classified by ICD; major malformation caused functional impairment and/or required surgical correction Main endpoint was growth (stature) | 1) Stature (height in cm, median [range[): | | | | Comments: None Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: +/ - (SC population younger [mat & pat], less likely primiparous) Verification that the control is free of cancer: NA Comparability of cases and controls with respect to potential confounders: +/- (see above) Validated dietary assessment method: NA Appropriateness of statistical analyses: +
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | ICSI | 112.4 (97.0–128.9)
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | SC | 112.0 (98.0–126.0)
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | 2) Major malformations:
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | | Major malform + | Major malform - | Total
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | ICSI | 20 | 280 | 300
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | SC | 8 | 258 | 266
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | Total | 28 | 538 | 566
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | | Value | Lower 95% CI | Upper 95% CI
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | Odds rat | 2.30 | 1.00 | 5.32
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | 3) Chronic illness:
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | | Chronic illness + | Chronic illness - | Total
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | ICSI | 24 | 276 | 300
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | SC | 18 | 248 | 266
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | Total | 42 | 524 | 566
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | | Value | Lower 95% CI | Upper 95% CI
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | Odds rat | 1.2 | 0.64 | 2.26
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | 4) LBW (< 2500 g):
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | | LBW + | LBW - | Total
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | ICSI | 32 | 268 | 300
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | SC | 10 | 256 | 266
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | Total | 42 | 524 | 566
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | | Value | Lower 95% CI | Upper 95% CI
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | Odds rat | 3.06 | 1.47 | 6.35
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | 5) Cesarean delivery (C/S):
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | | C/S + | C/S - | Total
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | ICSI | 74 | 226 | 300
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | SC | 38 | 228 | 266
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | Total | 112 | 454 | 566
Bonduelle, Bergh, Niklasson, et al., 2004 #11510 | | | | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.96 | 1.28 | 3.03
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | Geographical location: Brussels, Belgium Study dates: ICSI Jun 1991–Dec 1999 IVF Jan 1983–Dec 1999 Size of population: ICSI 3073 pregnancies, 2889 births IVF 3,329 pregnancies, 2995 births Study type: Cohort No correction for multiple comparisons because aiming to investigate safety of ICSI | Mat Age: Mean (SD): ICSI sing: 32.7 (4.3) ICSI multi: 32.8 (4.3) IVF sing: 32.4 (4.2) IVF multi: 31.7 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All pregnancies obtained by IVF or ICSI in single center Exclusion criteria: ICSI: 2.4% lost for f/u; IVF 2.6% lost | Definition(s) of outcome(s): Perinatal outcomes obtained from ob/gyn in charge; if any problem, detailed info obtained from peds. Babies born at “our hosp” had detailed exam and routine US of brain kidneys, and heart. For those born elsewhere, exam by geneticist done after 2 mo when possible. 2 mo f/u with parents to verify neonatal data, and collect info on illness & development. When possible, exam. 12mo & 2 y f/u as well. Major malformation = causes functional impairment or requires surgical correction. Minor malformation distinguished from normal if occurs in ≤ 4% of infants of same ethnic group | No difference in LBW, VLBW between singletons by IVF/ICSI. No diff in total perinatal death rates, major malformations in EABs and IUFDs. | | | | Comments:; - IVF group collected starting earlier; may bias outcomes in favor of ICSI because of advances since then; - Complete data given comparing rates of biochemical, ectopic pregnancies, SAB, EAB, IUFD, multiples - similar rates in both groups.; - More nullips & smokers in ICSI group; - Routine testing led to higher detection rates for malformations in IVF pts - difference disappeared when these patients excluded; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | The following 2 use livebirths as denominator.
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | 1) VLBW multiples:
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | | VLBW + | VLBW - | Total
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | ICSI | 103 | 1238 | 1341
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | IVF | 139 | 1260 | 1399
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | Total | 242 | 2498 | 2740
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | | Value | Lower 95% CI | Upper 95% CI
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | Rel risk | 0.77 | 0.61 | 0.99
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | 2) Prematurity < 37wks multiples (holds for total, but similar rates in singletons):
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | | Prem + | Prem - | Total
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | ICSI | 776 | 565 | 1341
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | IVF | 727 | 672 | 1399
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | Total | 1503 | 1237 | 2740
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | | Value | Lower 95% CI | Upper 95% CI
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | Rel risk | 1.11 | 1.04 | 1.19
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | 3) Major malformations:
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | | Major malf + | Major malf - | Total
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | ICSI | 96 | 2744 | 2840
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | IVF | 112 | 2843 | 2955
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | Total | 208 | 5587 | 5795
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | | Value | Lower 95% CI | Upper 95% CI
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | Rel risk | 0.89 | 0.68 | 1.17
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | No difference when separately analyzing or adding in EABs, IUFDs.
Bonduelle, Liebaers, Deketelaere, et al., 2002 #2650 | | | | No difference by method of sperm collection. No difference by sperm morphology.
Higher rates of major malformation with sperm motility < 50%, but raw data not shown (3.77% vs 1.86% for motility ≥ 50%).
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | Geographical location: Brussels, Belgium; Göteborg, Sweden; Copenhagen, Denmark; Thessaloniki, Greece; and London, UK Study dates: Nov 2000 – Nov 2002 Size of population: 1515 total 540 ICSI 437 IVF 538 NC (natural conception) Study type: 5-yr-old children conceived by ICSI, IVF, or NC were examined by pediatricians, & history taken from parents. NC controls matched for age, sex, maternal education, parental SES. | Age: Mean (SD): ICSI: 5.0 (0.3) IVF: 5.1 (0.3) NC: 5.1 (0.3) Race/ethnicity (n [%]): Caucasian 100 Diagnoses (n [%]): NR Inclusion criteria:; - Age 4.5–5.5 yr; - Singleton; - Caucasian; - Born ≥ 32 wk gestation; - 1^st^ or 2^nd^ born; - Mother tongue English, Dutch, Danish, Swedish, or Greek; Exclusion criteria: NR | Definition(s) of outcome(s): Illnesses & anomalies classified according to ICD Malformations classified into major & minor by geneticist blinded to mode of conception Major malformation = causes functional impairment or requires surgical correction | ANOVA was used by investigators to compare 3 grps, but results here presented with NC grp as referent grp | | | | Comments: ICSI, IVF cases recruited from fertility clinics; unclear exactly how, and unclear whether some may have refused participation (perhaps those with more problems were more likely to enroll) Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + (although see above) Appropriateness of the control population: + Verification that the control is free of cancer: NA Comparability of cases and controls with respect to potential confounders: - (NC group mat & pat age younger, less likely married, less likely to have any maternal chronic illness) Validated dietary assessment method: NA Appropriateness of statistical analyses: +
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | 1) Weight & height were similar among grps.
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | 2) Any surgery (ICSI vs. NC controls):
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | | Any surg + | Any surg - | Total
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | ICSI | 128 | 412 | 540
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | NC | 73 | 465 | 538
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | Total | 201 | 877 | 1078
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | | Value | Lower 95% CI | Upper 95% CI
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | Odds rat | 1.98 | 1.44 | 2.72
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | 3) Any surgery (IVF vs. NC controls):
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | | Any surg + | Any surg - | Total
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | IVF | 95 | 342 | 437
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | NC | 73 | 465 | 538
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | Total | 168 | 807 | 975
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | | Value | Lower 95% CI | Upper 95% CI
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | Odds rat | 1.77 | 1.27 | 2.47
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | 4) Major malformations (ICSI vs. NC controls):
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | | Major malform + | Major malform - | Total
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | ICSI | 33 | 507 | 540
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | NC | 12 | 526 | 538
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | Total | 45 | 1033 | 1078
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | | Value | Lower 95% CI | Upper 95% CI
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | Odds rat | 2.85 | 1.46 | 5.59
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | 5) Major malformations (IVF vs. NC controls):
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | | Major malform + | Major malform - | Total
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | ICSI | 18 | 419 | 437
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | NC | 12 | 526 | 538
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | Total | 30 | 945 | 975
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | | Value | Lower 95% CI | Upper 95% CI
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | Odds rat | 1.88 | 0.90 | 3.95
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | 6) Cesarean delivery (C/S - ICSI vs. NC controls):
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | | C/S + | C/S - | Total
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | ICSI | 155 | 385 | 540
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | NC | 95 | 443 | 538
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | Total | 250 | 828 | 1078
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | | Value | Lower 95% CI | Upper 95% CI
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | Odds rat | 1.88 | 1.41 | 2.51
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | 7) Cesarean delivery (IVF vs. NC controls):
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | | C/S + | C/S - | Total
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | IVF | 119 | 318 | 437
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | NC | 95 | 443 | 538
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | Total | 214 | 761 | 975
Bonduelle, Wennerholm, Loft, et al., 2005 #9680 | | | | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.75 | 1.29 | 2.37
Brinton, Kruger Kjaer, Thomsen, et al., 2004 #13420 | Geographical location: Copenhagen, Denmark Study dates: NR; mothers diagnosed with infertility 1960 - 1996 Size of population: 54,379 women identified with diagnosis of infertility 1960 - 1996 51,063 children born to 30,364 women from that cohort:; - 16,786 born before mother entered cohort (i.e., before diagnosis of infertility); - 34,277 born after entry into cohort; Total of 105 children diagnosed with cancer:; - 54 born before entry into cohort.; - 51 born after; Study type: Study compared rate of CA in above-described cohort of children to rate in the general population Also compared those with CA to children of “random subcohort” of 868 children (case-cohort) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women with diagnosis of infertility and the children born to those women Exclusion criteria: Stillbirths, foreign adoptions, Danish adoptions, births with uncertain nationality | Definition(s) of outcome(s): Expected number of tumors = person-yrs of observations * age-, sex-, and calendar-specific incidence rates for tumor occurrence SIR = standardized incidence ratio = ratio of observed/expected number of tumors | 1) CA risk of cases was found to be comparable to that of the general population in Denmark: | | | | Comments:; - Little bias - few records could not be obtained; - National database; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: NA Comparability of cases and controls with respect to potential confounders: - (not assessed) Validated dietary assessment method: NA Appropriateness of statistical analyses: +
Brinton, Kruger Kjaer, Thomsen, et al., 2004 #13420 | | | | Observed: 51
Brinton, Kruger Kjaer, Thomsen, et al., 2004 #13420 | | | | Expected: 44.7
Brinton, Kruger Kjaer, Thomsen, et al., 2004 #13420 | | | | SIR = 1.14 (95% CI 0.8 to 1.5)
Brinton, Kruger Kjaer, Thomsen, et al., 2004 #13420 | | | | 2) “Case-cohort” portion - childhood tumors by maternal exposure to ovulation-stimulating drugs:
Brinton, Kruger Kjaer, Thomsen, et al., 2004 #13420 | | | | | CA | Controls | Total
Brinton, Kruger Kjaer, Thomsen, et al., 2004 #13420 | | | | Ovul stim + | 15 | 334 | 349
Brinton, Kruger Kjaer, Thomsen, et al., 2004 #13420 | | | | Ovul stim - | 30 | 524 | 554
Brinton, Kruger Kjaer, Thomsen, et al., 2004 #13420 | | | | Total | 45 | 858 | 903
Brinton, Kruger Kjaer, Thomsen, et al., 2004 #13420 | | | | | Value | Lower 95% CI | Upper 95% CI
Brinton, Kruger Kjaer, Thomsen, et al., 2004 #13420 | | | | Odds rat | 0.78 | 0.42 | 1.48
No difference if broken down by clomid, hMG, or number of cycles of each. Some had unknown ovulation-stimulation, clomid, hMG status
Brinton, Lamb, Moghissi, et al., 2004 #13110 | Geographical location: Boston, MA; New York, NY; Chicago, IL; Detroit, MI; San Francisco, CA Study dates: Patients seen between 1965-1988 Size of population (no. of patients): 8429 analyzed (original pool 12,193) Study type: Cohort | Age: Age at evaluation < 30: 47.5% ≥ 30: 52.5% Race/ethnicity (n [%]): White: 6658 (79.0%) African-American: 393 (4.6%) Other: 471 (5.6%) Unknown: 908 (10.8%) Diagnoses (n [%]): Unexplained infertility: Endometriosis: 1893 (22.5%) Male factor: 1942 (23.0%) Tubal factor: 2954 (35.0%) PCOS: 2304 (27.3%) Uterine/cervical: 1516 (18.0%) Categories not mutually exclusive Inclusion criteria:; - evaluated for infertility at 1 of the participating clinics between 1965 and 1988,; - had a U.S. address at the time of evaluation,; - were seen more than once or had been referred by another physician who provided relevant medical information.; Exclusion criteria: Evaluated for reversal of tubal ligation | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | 1) Standardized Incidence Ratios: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Brinton, Lamb, Moghissi, et al., 2004 #13110 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | | SIR | 95% CI
Brinton, Lamb, Moghissi, et al., 2004 #13110 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | All subjects | 1.98 | 1.4, 2.6
Brinton, Lamb, Moghissi, et al., 2004 #13110 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Ever exposed:
Brinton, Lamb, Moghissi, et al., 2004 #13110 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Clomiphene
Brinton, Lamb, Moghissi, et al., 2004 #13110 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | No | 2.09 | 1.4,3.0
Brinton, Lamb, Moghissi, et al., 2004 #13110 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Yes | 1.79 | 1.0,3.0
Brinton, Lamb, Moghissi, et al., 2004 #13110 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Gonadotropins
Brinton, Lamb, Moghissi, et al., 2004 #13110 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | No | 1.95 | 1.4,2.7
Brinton, Lamb, Moghissi, et al., 2004 #13110 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Yes | 2.26 | 0.7,5.3
2) Adjusted within-group risks non-significantly higher in women with > 12 cycles clomiphene (OR 1.54, 95% CI 0.5, 5.1) or >9 cycles gonadotropins (OR 1.21, 95% CI 0.4, 3.9); or more than 15 years since exposure (clomiphene OR 1.48, 95% CI 0.7, 3.2; gonadotropin OR 2.46, 95% CI 0.7, 8.3). Risk also increased in women who were still nulliparous at follow-up (OR 1.75, 95% CI 0.5, 5.7). No other adjusted ORs above 1.2.
Brinton, Lamb, Moghissi, et al., 2004 #12620 | Geographical location: Boston, MA; New York, NY; Chicago, IL; Detroit, MI; San Francisco, CA Study dates: Patients seen between 1965-1988 Size of population (no. of patients): 8429 analyzed (original pool 12,193) Study type: Cohort | Age: Age at evaluation < 30: 47.5% ≥ 30: 52.5% Race/ethnicity (n [%]): White: 6658 (79.0%) African-American: 393 (4.6%) Other: 471 (5.6%) Unknown: 908 (10.8%) Diagnoses (n [%]): Unexplained infertility: Endometriosis: 1893 (22.5%) Male factor: 1942 (23.0%) Tubal factor: 2954 (35.0%) PCOS: 2304 (27.3%) Uterine/cervical: 1516 (18.0%) Categories not mutually exclusive Inclusion criteria:; - evaluated for infertility at 1 of the participating clinics between 1965 and 1988,; - had a U.S. address at the time of evaluation,; - were seen more than once or had been referred by another physician who provided relevant medical information.; Exclusion criteria: Evaluated for reversal of tubal ligation | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | 1) Standardized Incidence Ratios: | | | | Comments: May be variability in accuracy of exposure categorization (e.g., laparoscopic dx of endometriosis), but unlikely to be any bias in ascertainment between cases and non-cases Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Brinton, Lamb, Moghissi, et al., 2004 #12620 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | | SIR | 95% CI
Brinton, Lamb, Moghissi, et al., 2004 #12620 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Type of infertility
Brinton, Lamb, Moghissi, et al., 2004 #12620 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Primary | 2.73 | 1.8,4.0
Brinton, Lamb, Moghissi, et al., 2004 #12620 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Secondary | 1.44 | 0.9,2.2
Brinton, Lamb, Moghissi, et al., 2004 #12620 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Cause of infertility
Brinton, Lamb, Moghissi, et al., 2004 #12620 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Endometriosis | 2.48 | 1.3,4.2
Brinton, Lamb, Moghissi, et al., 2004 #12620 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Anovulation | 1.94 | 1.0,3.4
Brinton, Lamb, Moghissi, et al., 2004 #12620 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Tubal disease/adhesions | 2.04 | 1.2,3.3
Brinton, Lamb, Moghissi, et al., 2004 #12620 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Male factor | 1.88 | 0.9,3.5
Brinton, Lamb, Moghissi, et al., 2004 #12620 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Cervical factor | 1.32 | 0.2,4.8
Brinton, Lamb, Moghissi, et al., 2004 #12620 | | | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate | Uterine factor | 2.2 | 0.8,4.8
2) Within-group adjusted rate ratio higher for women with primary infertility. Highest risk seen with endometriosis (RR 2.72, 95% CI 1.1, 6.7)
Brinton, Scoccia, Moghissi, et al., 2004 #11150 | Geographical location: Boston, MA; New York, NY; Chicago, IL; Detroit, MI; San Francisco, CA Study dates: Patients seen between 1965-1988 Size of population (no. of patients): 8431 included in followup analysis (original pool 12,193) Study type: Cohort (retrospective) | Age: Age at evaluation < 30: 47.5% ≥ 30: 52.5% Race/ethnicity (n [%]): White: 6658 (79.0%) African-American: 393 (4.6%) Other: 471 (5.6%) Unknown: 908 (10.8%) Diagnoses (n [%]): Without/with CA (8139/292): Endometriosis: 1864/57 Male factor: 1875/78 Tubal factor: 2897/102 PCOS: 2238/85 Categories not mutually exclusive Inclusion criteria:; - Evaluated for infertility at participating clinic between 1965 and 1988; - U.S. address at the time of evaluation; - Seen more than once or referred by physician who provided relevant medical information; - Primary or secondary infertility; Exclusion criteria:; - Evaluated for reversal of tubal ligation; - Refused access to medical records | Definition(s) of outcome(s): Cancer cases ascertained by questionnaire, medical records, and cancer registries; confirmed if possible by medical records/registry/death certificate Standardized incidence ratios (SIRs) comparing breast cancer within infertility cohort with rates for U.S. women; observed/expected events based on age-, race-, and calendar-yr-specific incidence disease rates for females from CA registry rates through SEER. Standardized mortality ratios (SMRs) also calculated. | 1) Standardized Incidence Ratios - breast cancer: | | | | Comments:; - Retrospective - relied on review of medical records, unable to locate 20% of study pop, 11% refused permission to access records, 41% of those alive did not complete questionnaire; - Incomplete infertility workups - but adjustment for cause of infertility did not change risks; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: - Analysis (multivariate adjustments) and reporting of results: +:
Brinton, Scoccia, Moghissi, et al., 2004 #11150 | | | | | SIR | 95% CI
Brinton, Scoccia, Moghissi, et al., 2004 #11150 | | | | All subjects | 1.29 | 1.1, 1.4
Brinton, Scoccia, Moghissi, et al., 2004 #11150 | | | | Ever exposed:
Brinton, Scoccia, Moghissi, et al., 2004 #11150 | | | | Clomiphene
Brinton, Scoccia, Moghissi, et al., 2004 #11150 | | | | No | 1.28 | 1.1,1.5
Brinton, Scoccia, Moghissi, et al., 2004 #11150 | | | | Yes | 1.29 | 1.1,1.6
Brinton, Scoccia, Moghissi, et al., 2004 #11150 | | | | Gonadotropins
Brinton, Scoccia, Moghissi, et al., 2004 #11150 | | | | No | 1.28 | 1.1,1.4
Brinton, Scoccia, Moghissi, et al., 2004 #11150 | | | | Yes | 1.40 | 0.9,2.0
Brinton, Scoccia, Moghissi, et al., 2004 #11150 | | | | SMR 1.58 (95% CI 1.1 to 2.2), with no higher risk for those who took clomid vs. not.
Brinton, Scoccia, Moghissi, et al., 2004 #11150 | | | | Higher risk of breast CA associated with later ages at first birth, nulliparity, prior history of breast CA.
Brinton, Scoccia, Moghissi, et al., 2004 #11150 | | | | No variation in risk across causes of infertility.
2) Adjusted within-group risks (adjusted for age at follow-up, calendar year, site, and family history): clomiphene 1.02 (0.8, 1.3); gonadotropins 1.07 (0.7, 1.6). Risk estimates higher 20 years after exposure (clomiphene 1.39 (0.9,2.1), gonadotropins 1.54 (0.8, 3.2)
Bruinsma, Venn, Lancaster, et al., 2000 #8560 | Geographical location: Victoria, Australia Study dates: 1979-95 Size of population: 5249 births from 4,357 pregnancies Study type: Cohort Births conceived by ART linked to Victorian Cancer Registry | Age at end of f/u: Mean (SD): NR Median: 3yr, 9mos Range: 0–15yr Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Conceptions using ART at 2 clinics resulting in livebirth Exclusion criteria: Stillbirths, parents residing overseas or interstate | Definition(s) of outcome(s): Expected # cases = Victorian age-specific population-based cancer incidence 1982 - 1995 applied to person-yrs f/u in each age grp. Standardized incidence ratio (SIR) = observed:expected cases. | 1) Expected vs observed cases of CA: | | | | Comments:; - Reporting to this registry is mandated by law since 1981 - tiny # of births in series before then.; - Not clear whether these 2 clinics are the only ones performing ART in this area - if not, may have missed some cases and understated risk.; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: - Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Bruinsma, Venn, Lancaster, et al., 2000 #8560 | Geographical location: Victoria, Australia Study dates: 1979-95 Size of population: 5249 births from 4,357 pregnancies Study type: Cohort Births conceived by ART linked to Victorian Cancer Registry | | | | CA+ | CA- | Total
Bruinsma, Venn, Lancaster, et al., 2000 #8560 | Geographical location: Victoria, Australia Study dates: 1979-95 Size of population: 5249 births from 4,357 pregnancies Study type: Cohort Births conceived by ART linked to Victorian Cancer Registry | | | Observed | 6 | 5243 | 5249
Bruinsma, Venn, Lancaster, et al., 2000 #8560 | Geographical location: Victoria, Australia Study dates: 1979-95 Size of population: 5249 births from 4,357 pregnancies Study type: Cohort Births conceived by ART linked to Victorian Cancer Registry | | | Expected | 4.33 | 5244.67 | 5249
Bruinsma, Venn, Lancaster, et al., 2000 #8560 | Geographical location: Victoria, Australia Study dates: 1979-95 Size of population: 5249 births from 4,357 pregnancies Study type: Cohort Births conceived by ART linked to Victorian Cancer Registry | | | Total | 10.33 | 10487.67 | 10498
Bruinsma, Venn, Lancaster, et al., 2000 #8560 | Geographical location: Victoria, Australia Study dates: 1979-95 Size of population: 5249 births from 4,357 pregnancies Study type: Cohort Births conceived by ART linked to Victorian Cancer Registry | | | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.39 | 0.40 | 4.77
Buckett, Chian, Holzer, et al., 2007 #70550 | Geographical location: Montreal, Canada Study dates: Jan 1998–Dec 2003 Size of population (no. of patients): 782 infants, 688 mothers Study type: Cohort All in vitro maturation (n = 55), in vitro fertilization (n = 217), ICSI (n = 16) pregnancies and age- and parity matched controls (n = 344) | Age: Mean (SD): 33 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All pregnancies delivered at the McGill University Health Centre after assisted reproductive treatments (namely, IVM, IVF, or ICSI) with a birth weight of at least 500 g Exclusion criteria: NR | Definition(s) of outcome(s): Major and minor anomalies | 1) All malformations, in vitro maturation vs. spontaneous: | | | | Comments: More multiples in ART pregnancies Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | | Mal + | Mal - | Total
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | IVM | 5 | 50 | 55
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | Spont | 25 | 325 | 350
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | Total | 30 | 375 | 405
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | | Value | Lower 95% CI | Upper 95% CI
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | Rel risk | 1.27 | 0.51 | 3.18
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | 2) All malformations, IVF vs. spontaneous:
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | | Mal + | Mal - | Total
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | IVF | 17 | 200 | 217
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | Spont | 25 | 325 | 350
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | Total | 42 | 525 | 567
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | | Value | Lower 95% CI | Upper 95% CI
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | Rel risk | 1.10 | 0.61 | 1.98
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | 3) All malformations, ICSI vs. spontaneous:
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | | Mal + | Mal - | Total
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | ICSI | 17 | 143 | 160
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | Spont | 25 | 325 | 350
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | Total | 42 | 468 | 510
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | | Value | Lower 95% CI | Upper 95% CI
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | Rel risk | 1.49 | 0.83 | 2.68
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | 4) All malformations, any ART vs. spontaneous:
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | | Mal + | Mal - | Total
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | Any ART | 39 | 393 | 432
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | Spont | 25 | 325 | 350
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | Total | 64 | 718 | 782
Buckett, Chian, Holzer, et al., 2007 #70550 | | | Definition(s) of outcome(s): Major and minor anomalies | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.26 | 0.78 | 2.05
Burkman, Tang, Malone, et al., 2003 #16690 | Geographical location: Atlanta, Detroit, Los Angeles, Philadelphia, and Seattle. Study dates: Jul 1994–Apr 1998 Size of population (no. of patients): Cases: 4575 (516 sought care for infertility) Controls: 4682 (617 sought care for infertility) Study type: Case-control | Age: Cases, controls matched for age Race/ethnicity (n [%]): White: 65%, African-American: 35% (matched for race) Diagnoses (n [%]): NR Inclusion criteria: Cases: age 35 to 64 years; presence of histologically confirmed, primary invasive breast cancer with no prior invasive or in situ breast cancer history; US birth with residence at date of diagnosis in a study region; white or black race (including Hispanic ethnicity); a working telephone at the individual's residence at date of diagnosis; ability to be interviewed in English; and physical and mental capability to undergo the interview process Controls—same except for case-defining event Exclusion criteria: NR | Definition(s) of outcome(s): Invasive breast cancer, confirmed by medical records | 1) Overall OR for fertility drug use, ever vs never, controlled for age, race, study site: 0.9 (0.8, 1.2) | | | | Comments:; - Case control; - Exposure by self-report—potential for recall bias; - Multiple comparisons; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Comparability of cases and controls with respect to potential confounders: + Appropriateness of statistical analyses: +
Burkman, Tang, Malone, et al., 2003 #16690 | | | Definition(s) of outcome(s): Invasive breast cancer, confirmed by medical records | Restricted to diagnosis of infertility: 1.2 (0.8, 1.7)
Risk increased in women treated with hMG ≥ 6 months/cycles (ORs for all subgroups >2.0, 95% CIs do not include 1.0)
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | Geographical location: Bristol, UK Study dates: Jan 1987 – April 1991 Size of population: 154 couples Study type: Cohort ≥ 3 yr after last contact with Centre, questionnaire mailed. Nonresponders got 2^nd^ questionnaire & phone call | Age: Mean (SD): 34.5 (5.4) Median: 34 respondents, 35 nonrespondents Range: 24–44 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Couples who had treatment at study center Exclusion criteria: Stated desire for no further contact, non-UK address, known divorce or death of either partner, ongoing or previous legal proceedings between couple and Centre, current pts, h/o bilat tubal occlusion or azoospermia. After questionnaire, excluded 34/154 couples who had received tx elsewhere, and 4 with incomplete records | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | 19% of respondents conceived in 3 yrs. | | | | Comment:; - Response rate 44%.; - No diff btw respondents & nonrespondents in age, duration of infertility, nulliparity, success from IVF at Centre; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: - Analysis (multivariate adjustments) and reporting of results: -
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | 1) Spont preg by age:
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | | Preg+ | Preg- | Total
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | > 38 | 1 | 24 | 25
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | ≤ 38 | 27 | 64 | 91
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Total | 28 | 88 | 116
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | | Value | Lower 95% CI | Upper 95% CI
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Odds rat | 0.10 | 0.01 | 0.77
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | 2) Spont preg by duration of infertility before IVF (y):
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | | Preg+ | Preg- | Total
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | ≥ 3 | 18 | 73 | 91
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | < 3 | 10 | 10 | 20
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Total | 28 | 83 | 111
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | | Value | Lower 95% CI | Upper 95% CI
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Odds rat | 0.25 | 0.09 | 0.68
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | 3) Spont preg by primary vs secondary infertility:
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | | Preg+ | Preg- | Total
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Prim | 17 | 52 | 69
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Sec | 11 | 31 | 42
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Total | 28 | 83 | 111
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | | Value | Lower 95% CI | Upper 95% CI
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Odds rat | 0.92 | 0.38 | 2.22
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | 4) Spont preg by unexplained infert vs all other:
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | | Preg+ | Preg- | Total
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Unexp | 8 | 15 | 23
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Other | 20 | 73 | 93
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Total | 28 | 88 | 116
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | | Value | Lower 95% CI | Upper 95% CI
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Odds rat | 1.95 | 0.72 | 5.24
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | 5) Spont preg by tubal infert vs all other:
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | | Preg+ | Preg- | Total
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Tubal | 2 | 30 | 32
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Other | 26 | 58 | 84
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | Total | 28 | 88 | 116
Cahill, Meadowcroft, Akande, et al., 2005 #38890 | | | Definition(s) of outcome(s): Pregnancy following last contact with infertility center | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 0.15 | 0.03 | 0.67
Cai, Izumi, Koido, et al., 2006 #50830 | Geographical location: Japan Study dates: 1994-2003 Size of population (no. of patients): Twins N = 199 Spontaneous n = 97 Ovulation induction n = 28 IUI n = 24 IVF n = 50 Study type: Cohort | Age: Spontaneous 29.4 (4.6) Ovulation indx 30.8 (3.8) IUI 32.1 (2.4) IVF 33.5 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins ≥ 25 wks Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth ≤ 36 wks Intrauterine growth retardation <10^th^%ile for Japanese standards Birthweight discordance ≥ 25% difference Low birthweight < 2500 g | Grouped all ART for relative risk calculations here but results are provided for individual Art modalities, although small n for each subgroup | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Cai, Izumi, Koido, et al., 2006 #50830 | Geographical location: Japan Study dates: 1994-2003 Size of population (no. of patients): Twins N = 199 Spontaneous n = 97 Ovulation induction n = 28 IUI n = 24 IVF n = 50 Study type: Cohort | Age: Spontaneous 29.4 (4.6) Ovulation indx 30.8 (3.8) IUI 32.1 (2.4) IVF 33.5 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins ≥ 25 wks Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth ≤ 36 wks Intrauterine growth retardation <10^th^%ile for Japanese standards Birthweight discordance ≥ 25% difference Low birthweight < 2500 g | 1) Preterm birth any ART v. spontaneous:
Cai, Izumi, Koido, et al., 2006 #50830 | Geographical location: Japan Study dates: 1994-2003 Size of population (no. of patients): Twins N = 199 Spontaneous n = 97 Ovulation induction n = 28 IUI n = 24 IVF n = 50 Study type: Cohort | Age: Spontaneous 29.4 (4.6) Ovulation indx 30.8 (3.8) IUI 32.1 (2.4) IVF 33.5 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins ≥ 25 wks Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth ≤ 36 wks Intrauterine growth retardation <10^th^%ile for Japanese standards Birthweight discordance ≥ 25% difference Low birthweight < 2500 g | | ptb+ | ptb- | Total
Cai, Izumi, Koido, et al., 2006 #50830 | Geographical location: Japan Study dates: 1994-2003 Size of population (no. of patients): Twins N = 199 Spontaneous n = 97 Ovulation induction n = 28 IUI n = 24 IVF n = 50 Study type: Cohort | Age: Spontaneous 29.4 (4.6) Ovulation indx 30.8 (3.8) IUI 32.1 (2.4) IVF 33.5 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins ≥ 25 wks Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth ≤ 36 wks Intrauterine growth retardation <10^th^%ile for Japanese standards Birthweight discordance ≥ 25% difference Low birthweight < 2500 g | any ART | 47 | 55 | 102
Cai, Izumi, Koido, et al., 2006 #50830 | Geographical location: Japan Study dates: 1994-2003 Size of population (no. of patients): Twins N = 199 Spontaneous n = 97 Ovulation induction n = 28 IUI n = 24 IVF n = 50 Study type: Cohort | Age: Spontaneous 29.4 (4.6) Ovulation indx 30.8 (3.8) IUI 32.1 (2.4) IVF 33.5 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins ≥ 25 wks Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth ≤ 36 wks Intrauterine growth retardation <10^th^%ile for Japanese standards Birthweight discordance ≥ 25% difference Low birthweight < 2500 g | spontaneous | 55 | 42 | 97
Cai, Izumi, Koido, et al., 2006 #50830 | Geographical location: Japan Study dates: 1994-2003 Size of population (no. of patients): Twins N = 199 Spontaneous n = 97 Ovulation induction n = 28 IUI n = 24 IVF n = 50 Study type: Cohort | Age: Spontaneous 29.4 (4.6) Ovulation indx 30.8 (3.8) IUI 32.1 (2.4) IVF 33.5 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins ≥ 25 wks Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth ≤ 36 wks Intrauterine growth retardation <10^th^%ile for Japanese standards Birthweight discordance ≥ 25% difference Low birthweight < 2500 g | Total | 102 | 97 | 199
Cai, Izumi, Koido, et al., 2006 #50830 | Geographical location: Japan Study dates: 1994-2003 Size of population (no. of patients): Twins N = 199 Spontaneous n = 97 Ovulation induction n = 28 IUI n = 24 IVF n = 50 Study type: Cohort | Age: Spontaneous 29.4 (4.6) Ovulation indx 30.8 (3.8) IUI 32.1 (2.4) IVF 33.5 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins ≥ 25 wks Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth ≤ 36 wks Intrauterine growth retardation <10^th^%ile for Japanese standards Birthweight discordance ≥ 25% difference Low birthweight < 2500 g | | Value | Lower 95% CI | Upper 95% CI
Cai, Izumi, Koido, et al., 2006 #50830 | Geographical location: Japan Study dates: 1994-2003 Size of population (no. of patients): Twins N = 199 Spontaneous n = 97 Ovulation induction n = 28 IUI n = 24 IVF n = 50 Study type: Cohort | Age: Spontaneous 29.4 (4.6) Ovulation indx 30.8 (3.8) IUI 32.1 (2.4) IVF 33.5 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins ≥ 25 wks Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth ≤ 36 wks Intrauterine growth retardation <10^th^%ile for Japanese standards Birthweight discordance ≥ 25% difference Low birthweight < 2500 g | Rel risk | 0.81 | 0.62 | 1.07
Cai, Izumi, Koido, et al., 2006 #50830 | Geographical location: Japan Study dates: 1994-2003 Size of population (no. of patients): Twins N = 199 Spontaneous n = 97 Ovulation induction n = 28 IUI n = 24 IVF n = 50 Study type: Cohort | Age: Spontaneous 29.4 (4.6) Ovulation indx 30.8 (3.8) IUI 32.1 (2.4) IVF 33.5 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins ≥ 25 wks Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth ≤ 36 wks Intrauterine growth retardation <10^th^%ile for Japanese standards Birthweight discordance ≥ 25% difference Low birthweight < 2500 g | 2) IUGR any Art v. spontaneous:
Cai, Izumi, Koido, et al., 2006 #50830 | Geographical location: Japan Study dates: 1994-2003 Size of population (no. of patients): Twins N = 199 Spontaneous n = 97 Ovulation induction n = 28 IUI n = 24 IVF n = 50 Study type: Cohort | Age: Spontaneous 29.4 (4.6) Ovulation indx 30.8 (3.8) IUI 32.1 (2.4) IVF 33.5 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins ≥ 25 wks Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth ≤ 36 wks Intrauterine growth retardation <10^th^%ile for Japanese standards Birthweight discordance ≥ 25% difference Low birthweight < 2500 g | | iugr+ | iugr- | Total
Cai, Izumi, Koido, et al., 2006 #50830 | Geographical location: Japan Study dates: 1994-2003 Size of population (no. of patients): Twins N = 199 Spontaneous n = 97 Ovulation induction n = 28 IUI n = 24 IVF n = 50 Study type: Cohort | Age: Spontaneous 29.4 (4.6) Ovulation indx 30.8 (3.8) IUI 32.1 (2.4) IVF 33.5 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins ≥ 25 wks Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth ≤ 36 wks Intrauterine growth retardation <10^th^%ile for Japanese standards Birthweight discordance ≥ 25% difference Low birthweight < 2500 g | any ART | 26 | 76 | 102
Cai, Izumi, Koido, et al., 2006 #50830 | Geographical location: Japan Study dates: 1994-2003 Size of population (no. of patients): Twins N = 199 Spontaneous n = 97 Ovulation induction n = 28 IUI n = 24 IVF n = 50 Study type: Cohort | Age: Spontaneous 29.4 (4.6) Ovulation indx 30.8 (3.8) IUI 32.1 (2.4) IVF 33.5 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins ≥ 25 wks Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth ≤ 36 wks Intrauterine growth retardation <10^th^%ile for Japanese standards Birthweight discordance ≥ 25% difference Low birthweight < 2500 g | spontaneous | 14 | 83 | 97
Cai, Izumi, Koido, et al., 2006 #50830 | Geographical location: Japan Study dates: 1994-2003 Size of population (no. of patients): Twins N = 199 Spontaneous n = 97 Ovulation induction n = 28 IUI n = 24 IVF n = 50 Study type: Cohort | Age: Spontaneous 29.4 (4.6) Ovulation indx 30.8 (3.8) IUI 32.1 (2.4) IVF 33.5 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins ≥ 25 wks Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth ≤ 36 wks Intrauterine growth retardation <10^th^%ile for Japanese standards Birthweight discordance ≥ 25% difference Low birthweight < 2500 g | Total | 40 | 159 | 199
Cai, Izumi, Koido, et al., 2006 #50830 | Geographical location: Japan Study dates: 1994-2003 Size of population (no. of patients): Twins N = 199 Spontaneous n = 97 Ovulation induction n = 28 IUI n = 24 IVF n = 50 Study type: Cohort | Age: Spontaneous 29.4 (4.6) Ovulation indx 30.8 (3.8) IUI 32.1 (2.4) IVF 33.5 (3.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins ≥ 25 wks Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth ≤ 36 wks Intrauterine growth retardation <10^th^%ile for Japanese standards Birthweight discordance ≥ 25% difference Low birthweight < 2500 g | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.77 | 0.98 | 3.18
Cheang, Huang, Lee, et al., 2007 #70640 | Geographical location: Macau, Sanchung, and Taipei, Taiwan Study dates: Jan 1998–Dec 2004 Size of population (no. of patients): 782 Study type: Cohort Comparison of twins resulting from ART to twins resulting from reduction from higher order multiples after ART | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Multiple pregnancy after ART during time period Exclusion criteria: NR | Definition(s) of outcome(s): Birth weight Preterm labor/delivery | 1) Delivery prior to 28 weeks, twins reduced from higher order multiples vs. non reduced twins: | | | | Comments: No adjustment for maternal age Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: - Use of validated method for ascertaining exposure: + Use of validated method for +ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Cheang, Huang, Lee, et al., 2007 #70640 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Multiple pregnancy after ART during time period Exclusion criteria: NR | Definition(s) of outcome(s): Birth weight Preterm labor/delivery | | < 28 weeks | > 28 weeks | Total
Cheang, Huang, Lee, et al., 2007 #70640 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Multiple pregnancy after ART during time period Exclusion criteria: NR | Definition(s) of outcome(s): Birth weight Preterm labor/delivery | Reduced | 16 | 337 | 353
Cheang, Huang, Lee, et al., 2007 #70640 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Multiple pregnancy after ART during time period Exclusion criteria: NR | Definition(s) of outcome(s): Birth weight Preterm labor/delivery | Non-reduced | 7 | 382 | 389
Cheang, Huang, Lee, et al., 2007 #70640 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Multiple pregnancy after ART during time period Exclusion criteria: NR | Definition(s) of outcome(s): Birth weight Preterm labor/delivery | Total | 23 | 719 | 742
Cheang, Huang, Lee, et al., 2007 #70640 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Multiple pregnancy after ART during time period Exclusion criteria: NR | Definition(s) of outcome(s): Birth weight Preterm labor/delivery | | Value | Lower 95% CI | Upper 95% CI
Cheang, Huang, Lee, et al., 2007 #70640 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Multiple pregnancy after ART during time period Exclusion criteria: NR | Definition(s) of outcome(s): Birth weight Preterm labor/delivery | Rel risk | 2.52 | 1.05 | 6.05
Cheang, Huang, Lee, et al., 2007 #70640 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Multiple pregnancy after ART during time period Exclusion criteria: NR | Definition(s) of outcome(s): Birth weight Preterm labor/delivery | 2) Delivery prior to 36 weeks:
Cheang, Huang, Lee, et al., 2007 #70640 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Multiple pregnancy after ART during time period Exclusion criteria: NR | Definition(s) of outcome(s): Birth weight Preterm labor/delivery | | < 36 weeks | > 26 weeks | Total
Cheang, Huang, Lee, et al., 2007 #70640 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Multiple pregnancy after ART during time period Exclusion criteria: NR | Definition(s) of outcome(s): Birth weight Preterm labor/delivery | Reduced | 143 | 210 | 353
Cheang, Huang, Lee, et al., 2007 #70640 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Multiple pregnancy after ART during time period Exclusion criteria: NR | Definition(s) of outcome(s): Birth weight Preterm labor/delivery | Non-reduced | 127 | 262 | 389
Cheang, Huang, Lee, et al., 2007 #70640 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Multiple pregnancy after ART during time period Exclusion criteria: NR | Definition(s) of outcome(s): Birth weight Preterm labor/delivery | Total | 270 | 472 | 742
Cheang, Huang, Lee, et al., 2007 #70640 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Multiple pregnancy after ART during time period Exclusion criteria: NR | Definition(s) of outcome(s): Birth weight Preterm labor/delivery | | Value | Lower 95% CI | Upper 95% CI
Cheang, Huang, Lee, et al., 2007 #70640 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Multiple pregnancy after ART during time period Exclusion criteria: NR | Definition(s) of outcome(s): Birth weight Preterm labor/delivery | Rel risk | 1.24 | 1.03 | 1.50
3) Risk increased with increasing number of fetus pre-reduction; risk of discordancy also significantly increased. No difference in perinatal morbidity/mortality
Check, Choe, Katsoff, et al., 2005 #41000 | Geographical location: Camden, NJ Study dates: Jan 1997–Nov 2003 Size of population: 1445 clinical pregnancies from fresh ET, 975 from frozen ET Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - All IVF pregnancies in women up to age 49, including donor oocytes; - Transfers used 3d old embryos; Exclusion criteria: Pregnancies resulting from blastocyst transfers | Definition(s) of outcome(s): NR | 1) Ectopic pregnancy by fresh vs. frozen embryo transfer: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Check, Choe, Katsoff, et al., 2005 #41000 | Geographical location: Camden, NJ Study dates: Jan 1997–Nov 2003 Size of population: 1445 clinical pregnancies from fresh ET, 975 from frozen ET Study type: Cohort (retrospective) | | Definition(s) of outcome(s): NR | | Ect+ | Ect- | Total
Check, Choe, Katsoff, et al., 2005 #41000 | Geographical location: Camden, NJ Study dates: Jan 1997–Nov 2003 Size of population: 1445 clinical pregnancies from fresh ET, 975 from frozen ET Study type: Cohort (retrospective) | | Definition(s) of outcome(s): NR | Frozen | 20 | 955 | 975
Check, Choe, Katsoff, et al., 2005 #41000 | Geographical location: Camden, NJ Study dates: Jan 1997–Nov 2003 Size of population: 1445 clinical pregnancies from fresh ET, 975 from frozen ET Study type: Cohort (retrospective) | | Definition(s) of outcome(s): NR | Fresh | 38 | 1407 | 1445
Check, Choe, Katsoff, et al., 2005 #41000 | Geographical location: Camden, NJ Study dates: Jan 1997–Nov 2003 Size of population: 1445 clinical pregnancies from fresh ET, 975 from frozen ET Study type: Cohort (retrospective) | | Definition(s) of outcome(s): NR | Total | 58 | 2362 | 2420
Check, Choe, Katsoff, et al., 2005 #41000 | Geographical location: Camden, NJ Study dates: Jan 1997–Nov 2003 Size of population: 1445 clinical pregnancies from fresh ET, 975 from frozen ET Study type: Cohort (retrospective) | | Definition(s) of outcome(s): NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.78 | 0.46 | 1.33
Child, Henderson, and Tan, 2004 #13790 | Geographical location: Montreal, Canada Study dates: 2000 Size of population: 801 infertility pts (460 women, 341 men) Response rate 55% & 46%, respectively Study type: Prospective questionnaire | Age: Mean (SD): Women: 35.5 (5.1) Men: 38.0 (6.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Male & female pts attending tertiary fertility clinic Exclusion criteria: NR | Definition(s) of outcome(s): Asked whether pts considered that babies of multiple pregnancy are at increased risk compared with singletons Asked to state desired number of babies with next fertility treatment | 1) Questionnaire results: | | | | Comment:; - Questionnaire completed alone, w/o consulting partner; - 50% response rate; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): Large sample size: Adequate description of the cohort: Use of validated method for genomic test: Use of validated method for ascertaining clinical outcomes: Adequate follow-up period: Completeness of follow-up: Analysis (multivariate adjustments) and reporting of results:
Child, Henderson, and Tan, 2004 #13790 | Geographical location: Montreal, Canada Study dates: 2000 Size of population: 801 infertility pts (460 women, 341 men) Response rate 55% & 46%, respectively Study type: Prospective questionnaire | Age: Mean (SD): Women: 35.5 (5.1) Men: 38.0 (6.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Male & female pts attending tertiary fertility clinic Exclusion criteria: NR | | Multiple logistic regression used to identify independent variables associated with desire for multiple pregnancy; another with recognition of increased risks of multiple pregnancy as dependent variable.
Child, Henderson, and Tan, 2004 #13790 | Geographical location: Montreal, Canada Study dates: 2000 Size of population: 801 infertility pts (460 women, 341 men) Response rate 55% & 46%, respectively Study type: Prospective questionnaire | Age: Mean (SD): Women: 35.5 (5.1) Men: 38.0 (6.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Male & female pts attending tertiary fertility clinic Exclusion criteria: NR | | 41% of all pts considered multiple pregnancy an ideal outcome.
Child, Henderson, and Tan, 2004 #13790 | Geographical location: Montreal, Canada Study dates: 2000 Size of population: 801 infertility pts (460 women, 341 men) Response rate 55% & 46%, respectively Study type: Prospective questionnaire | Age: Mean (SD): Women: 35.5 (5.1) Men: 38.0 (6.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Male & female pts attending tertiary fertility clinic Exclusion criteria: NR | | 38.9% women, 36.4% men reported twins would be ideal (2%, 0.9% for triplets; 0.7%, 1.5% for quads).
Child, Henderson, and Tan, 2004 #13790 | Geographical location: Montreal, Canada Study dates: 2000 Size of population: 801 infertility pts (460 women, 341 men) Response rate 55% & 46%, respectively Study type: Prospective questionnaire | Age: Mean (SD): Women: 35.5 (5.1) Men: 38.0 (6.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Male & female pts attending tertiary fertility clinic Exclusion criteria: NR | | Increasing duration of infertility or history of ART associated with increase, and previous children or recognition of risks with decrease in desire for multiple pregnancy.
History of ART was only variable associated with recognition of increased risk in multiple pregnancy.
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | Age: Dichorionic Spontaneous 30.5 (3.9) IVF 32.9 (4.2) Monochorionic Spontaneous 30.0 (4.2) IVF 31.8 (2.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | 1) Preterm birth, dichorionic twins: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | PTB+ | PTB- | Total
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | IVF | 49 | 107 | 156
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | spontaneous | 45 | 148 | 193
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Total | 94 | 255 | 349
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | Value | Lower 95% CI | Upper 95% CI
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Rel risk | 1.35 | 0.95 | 1.90
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | 2) Preterm birth, monochorionic twins:
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | PTB+ | PTB- | Total
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | IVF | 10 | 24 | 34
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | spontaneous | 37 | 117 | 154
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Total | 47 | 141 | 188
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | Value | Lower 95% CI | Upper 95% CI
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Rel risk | 1.22 | 0.68 | 2.21
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | 3) Low birthweight, dichorionic:
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | lbwt+ | lbwt- | Total
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | IVF | 235 | 77 | 312
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | spontaneous | 268 | 118 | 386
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Total | 503 | 195 | 698
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | Value | Lower 95% CI | Upper 95% CI
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Rel risk | 1.08 | 0.99 | 1.19
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | 4) Low birthweight, monochorionic:
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | lbwt+ | lbwt- | Total
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | IVF | 38 | 30 | 68
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | spontaneous | 212 | 96 | 308
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Total | 250 | 126 | 376
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | Value | Lower 95% CI | Upper 95% CI
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Rel risk | 0.81 | 0.65 | 1.02
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | 5) NICU admission, dichorionic:
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | NICU+ | NICU- | Total
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | IVF | 164 | 148 | 312
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | spontaneous | 165 | 221 | 386
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Total | 329 | 369 | 698
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | Value | Lower 95% CI | Upper 95% CI
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Rel risk | 1.23 | 1.05 | 1.44
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | 6) NICU admission, monochorionic:
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | NICU+ | NICU- | Total
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | IVF | 24 | 44 | 68
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | spontaneous | 136 | 172 | 308
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Total | 160 | 216 | 376
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | Value | Lower 95% CI | Upper 95% CI
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Rel risk | 0.80 | 0.57 | 1.13
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | 7) RDS, dichorionic:
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | RDS+ | RDS- | Total
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | IVF | 27 | 285 | 312
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | spontaneous | 36 | 350 | 386
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Total | 63 | 635 | 698
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | Value | Lower 95% CI | Upper 95% CI
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Rel risk | 0.93 | 0.58 | 1.49
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | 8) RDS, monochorionic:
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | RDS+ | RDS- | Total
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | IVF | 4 | 64 | 68
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | spontaneous | 31 | 277 | 308
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | Total | 35 | 341 | 376
Choi, Kim, and Roh, 2006 #51090 | Geographical location: Seoul, S. Korea Study dates: 1994-2003 Size of population (no. of patients): TWINS Spontaneous 392 ART 206 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 34wks Low birthweight < 2.5kg NICU admission Respiratory distress syndrome | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.58 | 0.21 | 1.60
Chow, Benson, Racowsky, et al., 2001 #4760 | Geographical location: Boston, MA Study dates: May 1998–April 2000 Size of population (no. of patients): 464 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - 1^st^ trimester ultrasound; - Multiple gestations; - Mode of conception known; Exclusion criteria: NR | Definition(s) of outcome(s): Chorionicity of multiple gestation | 1) Relative risk of monochorionic pair, spontaneous vs ART pregnancy: | | | | Comments: Tertiary center—possibility of referral bias Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: - Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Chow, Benson, Racowsky, et al., 2001 #4760 | Geographical location: Boston, MA Study dates: May 1998–April 2000 Size of population (no. of patients): 464 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - 1^st^ trimester ultrasound; - Multiple gestations; - Mode of conception known; Exclusion criteria: NR | Definition(s) of outcome(s): Chorionicity of multiple gestation | | Out + | Out - | Total
Chow, Benson, Racowsky, et al., 2001 #4760 | Geographical location: Boston, MA Study dates: May 1998–April 2000 Size of population (no. of patients): 464 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - 1^st^ trimester ultrasound; - Multiple gestations; - Mode of conception known; Exclusion criteria: NR | Definition(s) of outcome(s): Chorionicity of multiple gestation | Spont | 31 | 79 | 110
Chow, Benson, Racowsky, et al., 2001 #4760 | Geographical location: Boston, MA Study dates: May 1998–April 2000 Size of population (no. of patients): 464 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - 1^st^ trimester ultrasound; - Multiple gestations; - Mode of conception known; Exclusion criteria: NR | Definition(s) of outcome(s): Chorionicity of multiple gestation | ART | 19 | 335 | 354
Chow, Benson, Racowsky, et al., 2001 #4760 | Geographical location: Boston, MA Study dates: May 1998–April 2000 Size of population (no. of patients): 464 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - 1^st^ trimester ultrasound; - Multiple gestations; - Mode of conception known; Exclusion criteria: NR | Definition(s) of outcome(s): Chorionicity of multiple gestation | Total | 50 | 414 | 464
Chow, Benson, Racowsky, et al., 2001 #4760 | Geographical location: Boston, MA Study dates: May 1998–April 2000 Size of population (no. of patients): 464 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - 1^st^ trimester ultrasound; - Multiple gestations; - Mode of conception known; Exclusion criteria: NR | Definition(s) of outcome(s): Chorionicity of multiple gestation | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 5.25 | 3.09 | 8.92
Chung, Coutifaris, Chalian, et al., 2006 #51140 | Geographical location: 2 sites in Pennsylvania, U.S. Study dates: 1999-2004 Size of population (no. of patients): 159 cases 276 controls Study type: Case-control | Age: Mean (SD): Cases: 33.25 (3.52) Controls: 33.41 (3.73) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF-ET pregnancies reaching 10–12 wks gestation; - Cases = preterm delivery < 37 weeks of gestation, LBW < 2500 g, or stillbirth after 1^st^ trimester; - Controls = normal weight, full-term live births; Exclusion criteria:; - Spontaneous abortions; - Ectopic pregnancies; - Gestations with > 3 fetuses; - Pregnancies resulting from other methods of ART | Definition(s) of outcome(s): See definition of cases and controls | 1) Association of OHSS with adverse outcome: | | | | Comments: None Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Comparability of cases and controls with respect to potential confounders: + Appropriateness of statistical analyses: +
Chung, Coutifaris, Chalian, et al., 2006 #51140 | Geographical location: 2 sites in Pennsylvania, U.S. Study dates: 1999-2004 Size of population (no. of patients): 159 cases 276 controls Study type: Case-control | | Definition(s) of outcome(s): See definition of cases and controls | | Cases | Controls | Total
Chung, Coutifaris, Chalian, et al., 2006 #51140 | Geographical location: 2 sites in Pennsylvania, U.S. Study dates: 1999-2004 Size of population (no. of patients): 159 cases 276 controls Study type: Case-control | | Definition(s) of outcome(s): See definition of cases and controls | OHSS + | 45 | 23 | 68
Chung, Coutifaris, Chalian, et al., 2006 #51140 | Geographical location: 2 sites in Pennsylvania, U.S. Study dates: 1999-2004 Size of population (no. of patients): 159 cases 276 controls Study type: Case-control | | Definition(s) of outcome(s): See definition of cases and controls | OHSS - | 114 | 253 | 367
Chung, Coutifaris, Chalian, et al., 2006 #51140 | Geographical location: 2 sites in Pennsylvania, U.S. Study dates: 1999-2004 Size of population (no. of patients): 159 cases 276 controls Study type: Case-control | | Definition(s) of outcome(s): See definition of cases and controls | Total | 159 | 276 | 435
Chung, Coutifaris, Chalian, et al., 2006 #51140 | Geographical location: 2 sites in Pennsylvania, U.S. Study dates: 1999-2004 Size of population (no. of patients): 159 cases 276 controls Study type: Case-control | | Definition(s) of outcome(s): See definition of cases and controls | | Value | Lower 95% CI | Upper 95% CI
Chung, Coutifaris, Chalian, et al., 2006 #51140 | Geographical location: 2 sites in Pennsylvania, U.S. Study dates: 1999-2004 Size of population (no. of patients): 159 cases 276 controls Study type: Case-control | | Definition(s) of outcome(s): See definition of cases and controls | Odds rat | 4.34 | 2.51 | 7.52
Chung, Coutifaris, Chalian, et al., 2006 #51140 | Geographical location: 2 sites in Pennsylvania, U.S. Study dates: 1999-2004 Size of population (no. of patients): 159 cases 276 controls Study type: Case-control | | Definition(s) of outcome(s): See definition of cases and controls | 2) Multiple gestation associated with adverse outcome:
Chung, Coutifaris, Chalian, et al., 2006 #51140 | Geographical location: 2 sites in Pennsylvania, U.S. Study dates: 1999-2004 Size of population (no. of patients): 159 cases 276 controls Study type: Case-control | | Definition(s) of outcome(s): See definition of cases and controls | | Cases | Controls | Total
Chung, Coutifaris, Chalian, et al., 2006 #51140 | Geographical location: 2 sites in Pennsylvania, U.S. Study dates: 1999-2004 Size of population (no. of patients): 159 cases 276 controls Study type: Case-control | | Definition(s) of outcome(s): See definition of cases and controls | Twins/triplets | 113 | 49 | 162
Chung, Coutifaris, Chalian, et al., 2006 #51140 | Geographical location: 2 sites in Pennsylvania, U.S. Study dates: 1999-2004 Size of population (no. of patients): 159 cases 276 controls Study type: Case-control | | Definition(s) of outcome(s): See definition of cases and controls | Singletons | 46 | 227 | 273
Chung, Coutifaris, Chalian, et al., 2006 #51140 | Geographical location: 2 sites in Pennsylvania, U.S. Study dates: 1999-2004 Size of population (no. of patients): 159 cases 276 controls Study type: Case-control | | Definition(s) of outcome(s): See definition of cases and controls | Total | 159 | 276 | 435
Chung, Coutifaris, Chalian, et al., 2006 #51140 | Geographical location: 2 sites in Pennsylvania, U.S. Study dates: 1999-2004 Size of population (no. of patients): 159 cases 276 controls Study type: Case-control | | Definition(s) of outcome(s): See definition of cases and controls | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 11.38 | 7.17 | 18.05
Clayton, Schieve, Peterson, et al., 2006 #60320 | Geographical location: U.S. - national registry Study dates: Jan 1999–Dec 2001 Size of population (no. of patients): 94,118 Demographics presented for fresh, non-donor cycles (n = 69,366) Study type: Cohort | Age: 55.0% < 35 years Race/ethnicity (n [%]): White: 53.6% African-American: 2.6% Asian: 2.9% Hispanic:3.7% Other: 0.1% Missing: 37.2% Diagnoses (n [%]): Unexplained infertility: 11.1% Endometriosis: 8.4% Male factor: 21.5% Tubal factor: 17.0% Ovulatory disorders: 6.3% Combined: 27.7% Inclusion criteria: Pregnancy reported to ART Registry within time period Exclusion criteria: Investigators excluded a small number of pregnancies that resulted from less common treatment options (< 1%). These uncommon options included:; - Procedures in which any combination of IVF-ET, gamete intrafallopian transfer (GIFT), or zygote intrafallopian transfer (ZIFT) were used for transfer (n = 176); - Procedures in which both frozen-thawed and freshly fertilized embryos were transferred (n = 120); - Procedures in which embryos from both donor and patient oocytes were transferred (n = 109); - GIFT and ZIFT procedures that involved either donor oocytes or frozen-thawed embryos (n = 170); - Pregnancies for which the improbable transfer of 15 or more embryos was reported (n = 7) | Definition(s) of outcome(s): Intrauterine pregnancy: documentation of one or more gestational sacs in uterine cavity Ectopic pregnancy: documentation of one or more sacs outside the uterine cavity Heterotopic pregnancy: Criteria for both intrauterine and ectopic pregnancy met | 1) Overall ectopic rate 2.1%; heterotopic rate 0.15% | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Clayton, Schieve, Peterson, et al., 2006 #60320 | | | | 2) In multivariate analysis, risk of ectopic significantly increased with:
Clayton, Schieve, Peterson, et al., 2006 #60320 | | | | | OR | Lower 95% CI | Upper 95% CI
Clayton, Schieve, Peterson, et al., 2006 #60320 | | | | Tubal factor | 2.01 | 1.68 | 2.41
Clayton, Schieve, Peterson, et al., 2006 #60320 | | | | Endometriosis | 1.30 | 1.04 | 1.62
Clayton, Schieve, Peterson, et al., 2006 #60320 | | | | Non-tubal female factor | 1.38 | 1.16 | 1.63
and significantly decreased with history of prior birth (OR 0.62, 95% CI 0.54, 0.72).
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | Age: IUP vs. heterotopic, N (%) < 30: 17,791 (13.4) vs. 30 (14.5) 30–34: 47,004 (35.4) vs. 84 (40.6) 35–37: 28,869 (21.8) vs. 45 (21.7) 38–40: 21,212 (16) vs. 31 (15.0) 41–43: 10,849 (8.2) vs. 11 (5.3) < 44: 6,935 (5.2) vs. 6 (2.9) Race/ethnicity (n [%]): IUP v. heterotopic, N (%) Black 3,013 (2.3) v. 9 (4.4) Hispanic 4,291 (3.2) v. 5 (2.4) Asian 3,698 (2.8) v. 6 (2.9) Other 109 (0.1) v. 0 Unknown 56,108 (42.3) v. 79 (38.2) Diagnoses (n [%]): Tubal factor: 27,320 (20.6) v. 69 (33.3) Tubal Ligation: 3,339 (2.5) v. 6 (2.9) Endometriosis: 12,620 (9.5) v. 19 (9.2) Nontubal female factors: 64,344 (48.5) v. 95 (45.9) Male factor: 25,037 (18.9) v. 18 (8.7) Inclusion criteria: Reported to SART Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | 1) Sab by heterotopic vs. IUP-only: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | | SAb+ | SAb- | Total
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | Heterotopic | 64 | 140 | 204
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | IUP | 20147 | 111297 | 131444
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | Total | 20211 | 111437 | 131648
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | | Value | Lower 95% CI | Upper 95% CI
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | Rel risk | 2.05 | 1.67 | 2.51
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | 2) Livebirth by heterotopic vs. IUP-only:
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | | Livebirth+ | Livebirth- | Total
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | Heterotopic | 119 | 85 | 204
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | IUP | 109343 | 22101 | 131444
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | Total | 109462 | 22186 | 131648
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | | Value | Lower 95% CI | Upper 95% CI
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | Rel risk | 0.70 | 0.62 | 0.79
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | 3) Low birthweight by heterotopic vs. IUP-only among singleton livebirths only:
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | | Lbwt + | Lbwt - | Total
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | Heterotopic | 10 | 88 | 98
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | IUP | 6400 | 64300 | 70700
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | Total | 6410 | 64388 | 70798
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | | Value | Lower 95% CI | Upper 95% CI
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | Rel risk | 1.13 | 0.63 | 2.03
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | 4) Preterm birth by heterotopic vs. IUP-only among singleton livebirths only:
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | | Preterm + | Preterm - | Total
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | Heterotopic | 19 | 79 | 98
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | IUP | 9834 | 60866 | 70700
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | Total | 9853 | 60945 | 70798
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | | Value | Lower 95% CI | Upper 95% CI
Clayton, Schieve, Peterson, et al., 2007 #51210 | Geographical location: United States Study dates: 1999-2002 Size of population (no. of patients): 207 heterotopic 132,660 intrauterine-only Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion Preterm birth < 37 wk Low birthweight< 2500 gm | Rel risk | 1.39 | 0.93 | 2.09
Results for twins presented but cannot exactly reconcile # livebirths and outcomes based on # pregnancies vs. #neonates.
Cusido, Fabregas, Pere, et al., 2007 #70740 | Geographical location: Barcelona, Spain Study dates: Jan 1982–Dec 2000 Size of population (no. of patients): 42 case, 257 controls Study type: Case-control All borderline ovarian tumors vs. all benign pathology ovarian surgery | Age: Mean (SD): Cases: 39.5 (13.6) Controls: 37.0 (8.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Surgery for benign or borderline tumors during time period Exclusion criteria: NR | Definition(s) of outcome(s): | 1) History of infertility: | | | | Comments:; - No multivariate analysis; - Hospital-based controls; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: - Comparability of cases and controls with respect to potential confounders: - Appropriateness of statistical analyses: -
Cusido, Fabregas, Pere, et al., 2007 #70740 | | | Definition(s) of outcome(s): | | Borderline | Benign | Total
Cusido, Fabregas, Pere, et al., 2007 #70740 | | | Definition(s) of outcome(s): | Infert | 6 | 70 | 76
Cusido, Fabregas, Pere, et al., 2007 #70740 | | | Definition(s) of outcome(s): | No infert | 36 | 187 | 223
Cusido, Fabregas, Pere, et al., 2007 #70740 | | | Definition(s) of outcome(s): | Total | 42 | 257 | 299
Cusido, Fabregas, Pere, et al., 2007 #70740 | | | Definition(s) of outcome(s): | | Value | Lower 95% CI | Upper 95% CI
Cusido, Fabregas, Pere, et al., 2007 #70740 | | | Definition(s) of outcome(s): | Odds rat | 0.45 | 0.18 | 1.10
Cusido, Fabregas, Pere, et al., 2007 #70740 | | | Definition(s) of outcome(s): | | Borderline | Benign | Total
Cusido, Fabregas, Pere, et al., 2007 #70740 | | | Definition(s) of outcome(s): | Infert | 5 | 34 | 39
Cusido, Fabregas, Pere, et al., 2007 #70740 | | | Definition(s) of outcome(s): | No infert | 37 | 223 | 260
Cusido, Fabregas, Pere, et al., 2007 #70740 | | | Definition(s) of outcome(s): | Total | 42 | 257 | 299
Cusido, Fabregas, Pere, et al., 2007 #70740 | | | Definition(s) of outcome(s): | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 0.89 | 0.33 | 2.41
Da Costa, Abdelmassih, de Oliveira, et al. 2001 #5800 | Geographical location: Sao Paulo, Brazil Study dates: Jan 1996 – Dec 1999 Size of population: 943 pregnancies (129 from blastocyst transfers, 814 from 4–8cell) Study type: Cohort (retrospective) | Age: Mean (SD): 4–8cell grp 34.11 (3.53), Blastocyst 35.72 (4.67) Race/ethnicity (n [%]): NR Diagnoses (n [%]): 4–8cell grp, blastocyst grp Unexplained infertility: 233 (9), 27 (8) Endometriosis: 155 (6), 23 (7) Male factor: 956 (37), 131 (39) Tubal factor: 672 (26), 80 (24) PCOS: 465 (18), 54 (16) Other (specify): “other” 103 (4), 20 (6) Inclusion criteria: ICSI pregnancies Exclusion criteria: NR | Definition(s) of outcome(s): Monozygotic twinning | 1) Blastocyst versus 4–8cell transfer as risk factor for MZ twinning: | | | | Comments: Blastocyst transfer only performed during latter part of study period (from Sept 1998 on) Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for genomic test: n/a Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Da Costa, Abdelmassih, de Oliveira, et al. 2001 #5800 | Geographical location: Sao Paulo, Brazil Study dates: Jan 1996 – Dec 1999 Size of population: 943 pregnancies (129 from blastocyst transfers, 814 from 4–8cell) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning | | MZ+ | MZ- | Total
Da Costa, Abdelmassih, de Oliveira, et al. 2001 #5800 | Geographical location: Sao Paulo, Brazil Study dates: Jan 1996 – Dec 1999 Size of population: 943 pregnancies (129 from blastocyst transfers, 814 from 4–8cell) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning | blastocyst | 5 | 124 | 129
Da Costa, Abdelmassih, de Oliveira, et al. 2001 #5800 | Geographical location: Sao Paulo, Brazil Study dates: Jan 1996 – Dec 1999 Size of population: 943 pregnancies (129 from blastocyst transfers, 814 from 4–8cell) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning | 4–8 cell | 6 | 808 | 814
Da Costa, Abdelmassih, de Oliveira, et al. 2001 #5800 | Geographical location: Sao Paulo, Brazil Study dates: Jan 1996 – Dec 1999 Size of population: 943 pregnancies (129 from blastocyst transfers, 814 from 4–8cell) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning | Total | 11 | 932 | 943
Da Costa, Abdelmassih, de Oliveira, et al. 2001 #5800 | Geographical location: Sao Paulo, Brazil Study dates: Jan 1996 – Dec 1999 Size of population: 943 pregnancies (129 from blastocyst transfers, 814 from 4–8cell) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 5.26 | 1.63 | 16.98
Daniel, Ochshorn, Fait, et al. 2000 #6840 | Geographical location: Tel Aviv, Israel Study dates: Jan 1996 – Dec 1997 Size of population: 297 twin pregnancies (104 by ART, 193 by non-ART, of which 72 conceived by ovulation induction and 121 spontaneously) Study type: Cohort (retrospective) Compared all twins ≥ 24wks born at one hosp, ART versus NC | Age: Mean (SD): ART 32 (4.8), non-ART 30.4 (4.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin pregnancies delivered ≥ 24wks. Exclusion criteria: HOM with or w/o IUFD, singletons with early vanishing twins, twin pregnancies reduced to singletons | Definition(s) of outcome(s): PIH = persistent BP ≥ 140/90 > 20wks in previously normotensive Preex = same plus proteinuria ≥ 100mg/dL or 300mg/24h Preterm uterine ctx = regular ctxs requiring tocolytics (accompanied by progressive cvx change and/or dil > 1cm at admission) Discordance > 25% birthwt IUGR < 3%ile or no wt gain in 2–3wks | Note raw data not given, only percentages | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for genomic test: n/a Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | 1) IUGR, ART vs non-ART:
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | | IUGR+ | IUGR- | Total
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | ART | 8 | 99 | 107
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | non-ART | 5 | 188 | 193
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | Total | 13 | 287 | 300
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | | Value | Lower 95% CI | Upper 95% CI
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | Odds rat | 3.04 | 0.97 | 9.53
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | ART vs spont also ns
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | 2) Discordance, ART vs non-ART:
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | | disc+ | disc- | Total
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | ART | 18 | 86 | 104
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | non-ART | 14 | 179 | 193
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | Total | 32 | 265 | 297
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | | Value | Lower 95% CI | Upper 95% CI
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | Odds rat | 2.68 | 1.27 | 5.63
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | 3) Fetal reduction, ART vs non-ART:
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | | Red+ | Red- | Total
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | ART | 23 | 81 | 104
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | non-ART | 5 | 188 | 193
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | Total | 28 | 269 | 297
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | | Value | Lower 95% CI | Upper 95% CI
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | Odds rat | 10.68 | 3.92 | 29.07
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | 3) Fetal reduction, ART vs ovulation indxn:
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | | Red+ | Red- | Total
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | ART | 23 | 81 | 104
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | OI | 5 | 67 | 72
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | Total | 28 | 148 | 176
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | | Value | Lower 95% CI | Upper 95% CI
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | Odds rat | 3.80 | 1.37 | 10.55
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | (no reductions in spontaneous grp)
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | 4) Cesarean, ART vs non-ART:
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | | C/S+ | C/S- | Total
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | ART | 45 | 59 | 104
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | non-ART | 65 | 128 | 193
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | Total | 110 | 187 | 297
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | | Value | Lower 95% CI | Upper 95% CI
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | Odds rat | 1.50 | 0.92 | 2.45
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | 5) PIH, ART vs non-ART:
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | | PIH+ | PIH- | Total
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | ART | 19 | 85 | 104
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | non-ART | 18 | 175 | 193
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | Total | 37 | 260 | 297
Daniel, Ochshorn, Fait, et al. 2000 #6840 | | | | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 2.17 | 1.08 | 4.35
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | Geographical location: Amsterdam, Netherlands Study dates: Treated for IVF 1983-95 Questionnaire 1997-2000 Size of population: 7842 women, 4072 with regular menstrual cycles Study type: Cohort (retrospective) Questionnaire, and data abstracted retrospectively if consent given | Age: Mean (SD) at questionnaire, by cause of subfertility: Tubal: 33.3 (4.6) Male: 37.5 (4.4) Unexplained: 38.7 (4.3) Other: 38.6 (4.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF-treated women participating in OMEGA study Exclusion criteria:; - Did not consent; - 1^st^ cycle stimulation protocol unknown or Clomid; - Donor oocytes; - F/u period < 1yr Unable to assess menopausal status; - OC's 1 yr before questionnaire; - Induced menopause; - Pregnancy; - Lactation | Definition(s) of outcome(s): Women considered to be in menopause transition if; 1) mean menstrual cycle length was < 21 d or > 35 d and next cycle was not predictable within 4 d OR; 2) no menses in previous 3–11 mo OR; 3) used hormone therapy to manage menopause symptoms; Considered to have reached menopause when last VB occurred ≥ 12 mo before completion of questionnaire | 1) Menopause transition or menopause, by tubal vs. all other causes: | | | | Comments:; - 71% response rate; - No mention that those abstracting data were blinded to cause of subfertility; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - cohort: + Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: - Completeness of follow-up: - Analysis (multivariate adjustments) and reporting of results: -
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | | Men + | Men - | Total
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | Tubal | 133 | 1260 | 1393
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | Other | 157 | 2375 | 2532
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | Total | 290 | 3635 | 3925
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | | Value | Lower 95% CI | Upper 95% CI
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | Rel risk | 1.54 | 1.23 | 1.92
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | 2) Menopause transition or menopause, by male vs. all other causes:
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | | Men+ | Men- | Total
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | Male | 64 | 1156 | 1220
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | Other | 226 | 2479 | 2705
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | Total | 290 | 3635 | 3925
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | | Value | Lower 95% CI | Upper 95% CI
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | Rel risk | 0.63 | 0.48 | 0.82
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | 3) Menopause transition or menopause, by unexplained vs. all other causes:
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | | Men+ | Men- | Total
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | Unexp | 57 | 829 | 886
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | Other | 233 | 2806 | 3039
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | Total | 290 | 3635 | 3925
de Boer, den Tonkelaar, Burger, et al., 2005 #39440 | | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.84 | 0.63 | 1.11
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | Geographical location: Belgium Study dates: 1998-2003 Size of population (no. of patients): N = 251 singletons SET N = 59,535 spontaneous singletons Number of cycles analyzed: 808 Number of cycles per patient: 3.2 cycles/patient Study type: Cohort | Age: Mean (SD): SET: 30.8 (3.6) Spontaneous: 29.3 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 10% Female factor: 22.5% Male factor: 50% Mixed: 8.5% Inclusion criteria: Single embryo transfer (SET) with IVF+/-ICSI Exclusion criteria:; - Incomplete data; - Multiple gestations | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | 1) Low birthweight: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | | LBWT + | LBWT - | Total
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | SET | 15 | 236 | 251
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | Spontaneous | 3050 | 56485 | 59535
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | Total | 3065 | 56721 | 59786
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | | Value | Lower 95% CI | Upper 95% CI
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | Rel risk | 1.17 | 0.71 | 1.91
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | 2) Very low birthweight:
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | | VLBWT + | VLBWT - | Total
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | SET | 2 | 249 | 251
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | Spontaneous | 466 | 59069 | 59535
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | Total | 468 | 59318 | 59786
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | | Value | Lower 95% CI | Upper 95% CI
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | Rel risk | 1.02 | 0.26 | 4.06
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | 3) Preterm birth < 37 wk:
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | | PTB + | PTB - | Total
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | SET | 25 | 226 | 251
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | Spontaneous | 3669 | 55866 | 59535
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | Total | 3694 | 56092 | 59786
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | | Value | Lower 95% CI | Upper 95% CI
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | Rel risk | 1.62 | 1.11 | 2.35
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | 4) Very preterm birth:
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | | VPTB + | VPTB - | Total
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | SET | 2 | 249 | 251
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | Spontaneous | 468 | 59067 | 59535
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | Total | 470 | 59316 | 59786
De Neubourg, Gerris, Mangelschots, et al., 2006 #51450 | | | Definition(s) of outcome(s): Low birthweight < 2.5 kg Very low bwt < 1.5 kg Preterm birth < 37 wk Very preterm birth < 32 wk | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.01 | 0.25 | 4.04
De Neubourg, Mandelschots, Van Royen, et al., 2004 #11670 | Geographical location: Antwerp, Belgium Study dates: Jan 1998 – Dec 2002 Size of population: 27 cases OHSS in 2007 cycles, 21 during conception cycles 16/482 singleton 5/134 twin Study type: Retrospective cohort study | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: OHSS recorded in database, occurring in conception cycle Exclusion criteria: NR | Definition(s) of outcome(s): OHSS defined by Golan criteria; those with moderate or severe OHSS requiring hospitalization were recorded in database | 1) OHSS - twins vs. singletons: | | | | Comment:; - Relies on OHSS cases being recorded into database; - No info regarding severity of OHSS (different between twins & singletons?); - During this time period, single embryo transfer was “gradually introduced” - but no data presented to assess correlation between number of embryos transferred & OHSS; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for genomic test: NA Use of validated method for ascertaining clinical outcomes: (Golan criteria) Adequate follow-up period: NA Completeness of follow-up: NA Analysis (multivariate adjustments) and reporting of results: -
De Neubourg, Mandelschots, Van Royen, et al., 2004 #11670 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: OHSS recorded in database, occurring in conception cycle Exclusion criteria: NR | Definition(s) of outcome(s): OHSS defined by Golan criteria; those with moderate or severe OHSS requiring hospitalization were recorded in database | | OHSS + | OHSS - | Total
De Neubourg, Mandelschots, Van Royen, et al., 2004 #11670 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: OHSS recorded in database, occurring in conception cycle Exclusion criteria: NR | Definition(s) of outcome(s): OHSS defined by Golan criteria; those with moderate or severe OHSS requiring hospitalization were recorded in database | Twin | 5 | 129 | 134
De Neubourg, Mandelschots, Van Royen, et al., 2004 #11670 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: OHSS recorded in database, occurring in conception cycle Exclusion criteria: NR | Definition(s) of outcome(s): OHSS defined by Golan criteria; those with moderate or severe OHSS requiring hospitalization were recorded in database | Singleton | 16 | 366 | 382
De Neubourg, Mandelschots, Van Royen, et al., 2004 #11670 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: OHSS recorded in database, occurring in conception cycle Exclusion criteria: NR | Definition(s) of outcome(s): OHSS defined by Golan criteria; those with moderate or severe OHSS requiring hospitalization were recorded in database | Total | 21 | 495 | 516
De Neubourg, Mandelschots, Van Royen, et al., 2004 #11670 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: OHSS recorded in database, occurring in conception cycle Exclusion criteria: NR | Definition(s) of outcome(s): OHSS defined by Golan criteria; those with moderate or severe OHSS requiring hospitalization were recorded in database | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.89 | 0.33 | 2.38
De Sutter, Delbaere, Gerris, et al., 2006 #51480 | Geographical location: Finland Study dates: 2000-4 Size of population (no. of patients): N = 404 single ET N =431 double ET Study type: Cohort | Age: Mean (SD): SET 31.6 (3.5) DET 33.2 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): SET vs. DET groups: Unexplained infertility: 118 (29.6%), 81 (19%) Female: 66 (16.6%), 63 (14.8%) Male factor: 184 (46.2%), 244 (57.1%) Combined: 30 (7.5%), 39 (9.1%) Inclusion criteria: Single or double fresh embryo transfer in cycle 1–3, who delivered a singleton child of > 500 g Exclusion criteria: NR | Definition(s) of outcome(s): Outcomes were not defined Preterm birth Low birthweight | 1) Preterm birth: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
De Sutter, Delbaere, Gerris, et al., 2006 #51480 | Geographical location: Finland Study dates: 2000-4 Size of population (no. of patients): N = 404 single ET N =431 double ET Study type: Cohort | | Definition(s) of outcome(s): Outcomes were not defined Preterm birth Low birthweight | | PTB + | PTB -
De Sutter, Delbaere, Gerris, et al., 2006 #51480 | Geographical location: Finland Study dates: 2000-4 Size of population (no. of patients): N = 404 single ET N =431 double ET Study type: Cohort | | Definition(s) of outcome(s): Outcomes were not defined Preterm birth Low birthweight | DET | 45 | 386 | 431
De Sutter, Delbaere, Gerris, et al., 2006 #51480 | Geographical location: Finland Study dates: 2000-4 Size of population (no. of patients): N = 404 single ET N =431 double ET Study type: Cohort | | Definition(s) of outcome(s): Outcomes were not defined Preterm birth Low birthweight | SET | 25 | 379 | 404
De Sutter, Delbaere, Gerris, et al., 2006 #51480 | Geographical location: Finland Study dates: 2000-4 Size of population (no. of patients): N = 404 single ET N =431 double ET Study type: Cohort | | Definition(s) of outcome(s): Outcomes were not defined Preterm birth Low birthweight | | 70 | 765 | 835
De Sutter, Delbaere, Gerris, et al., 2006 #51480 | Geographical location: Finland Study dates: 2000-4 Size of population (no. of patients): N = 404 single ET N =431 double ET Study type: Cohort | | Definition(s) of outcome(s): Outcomes were not defined Preterm birth Low birthweight | | | Lower 95% CI | Upper 95 % CI
De Sutter, Delbaere, Gerris, et al., 2006 #51480 | Geographical location: Finland Study dates: 2000-4 Size of population (no. of patients): N = 404 single ET N =431 double ET Study type: Cohort | | Definition(s) of outcome(s): Outcomes were not defined Preterm birth Low birthweight | Rel risk | 1.69 | 1.05 | 2.70
De Sutter, Delbaere, Gerris, et al., 2006 #51480 | Geographical location: Finland Study dates: 2000-4 Size of population (no. of patients): N = 404 single ET N =431 double ET Study type: Cohort | | Definition(s) of outcome(s): Outcomes were not defined Preterm birth Low birthweight | 2) Low birthweight:
De Sutter, Delbaere, Gerris, et al., 2006 #51480 | Geographical location: Finland Study dates: 2000-4 Size of population (no. of patients): N = 404 single ET N =431 double ET Study type: Cohort | | Definition(s) of outcome(s): Outcomes were not defined Preterm birth Low birthweight | | LBW | Preg -
De Sutter, Delbaere, Gerris, et al., 2006 #51480 | Geographical location: Finland Study dates: 2000-4 Size of population (no. of patients): N = 404 single ET N =431 double ET Study type: Cohort | | Definition(s) of outcome(s): Outcomes were not defined Preterm birth Low birthweight | DET | 50 | 381 | 431
De Sutter, Delbaere, Gerris, et al., 2006 #51480 | Geographical location: Finland Study dates: 2000-4 Size of population (no. of patients): N = 404 single ET N =431 double ET Study type: Cohort | | Definition(s) of outcome(s): Outcomes were not defined Preterm birth Low birthweight | SET | 17 | 387 | 404
De Sutter, Delbaere, Gerris, et al., 2006 #51480 | Geographical location: Finland Study dates: 2000-4 Size of population (no. of patients): N = 404 single ET N =431 double ET Study type: Cohort | | Definition(s) of outcome(s): Outcomes were not defined Preterm birth Low birthweight | | 67 | 768 | 835
De Sutter, Delbaere, Gerris, et al., 2006 #51480 | Geographical location: Finland Study dates: 2000-4 Size of population (no. of patients): N = 404 single ET N =431 double ET Study type: Cohort | | Definition(s) of outcome(s): Outcomes were not defined Preterm birth Low birthweight | | | Lower 95% CI | Upper 95 % CI
De Sutter, Delbaere, Gerris, et al., 2006 #51480 | Geographical location: Finland Study dates: 2000-4 Size of population (no. of patients): N = 404 single ET N =431 double ET Study type: Cohort | | Definition(s) of outcome(s): Outcomes were not defined Preterm birth Low birthweight | Rel risk | 2.76 | 1.62 | 4.70
3) Risks remained statistically significant and elevated after adjustment for relevant confounders (including gestational age for birthweight).
De Sutter, Veldeman, Kok, et al., 2005 #41930 | Geographical location: Gent, Belgium Study dates: 1997-2001 Size of population: 126 pairs of pts (126 IVF, 126 IUI) Study type: Case-control Matched eligible IUI pts with IVF pts by maternal age, parity, plurality, del date | Age: Mean (SD): IVF: 31.7 (1.8) IUI: 30.3 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Patients who conceived by IVF or IUI; - Address available; Exclusion criteria:; - ICSI; - Incomplete questionnaire; - Non-respondents; - No appropriate control | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | No difference in C/S rate (raw #s not reported) | | | | Comments:; - Only 47% of IUI pts responded to initial questionnaire; - Small numbers - not able to detect rare outcomes; - No mention of those collecting data being blinded to mode of conception; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: - Appropriateness of the control population: + Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: - (not matched for smoking, adverse pregnancy history, medical problems) Validated dietary assessment method: NR Appropriateness of statistical analyses: +
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | 1) Preterm birth:
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | | PTB + | PTB - | Total
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | IVF | 21 | 105 | 126
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | IUI | 19 | 107 | 126
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | Total | 40 | 212 | 252
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | | Value | Lower 95% CI | Upper 95% CI
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | Odds rat | 1.13 | 0.57 | 2.22
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | 2) NICU stay:
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | | NICU + | NICU - | Total
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | IVF | 16 | 110 | 126
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | IUI | 24 | 102 | 126
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | Total | 40 | 212 | 252
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | | Value | Lower 95% CI | Upper 95% CI
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | Odds rat | 0.62 | 0.31 | 1.23
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | 3) PIH:
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | | PIH + | PIH - | Total
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | IVF | 19 | 107 | 126
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | IUI | 12 | 114 | 126
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | Total | 31 | 221 | 252
De Sutter, Veldeman, Kok, et al., 2005 #41930 | | | Definition(s) of outcome(s): PTB < 37 wk LBW < 2500 g Perinatal mortality= stillbirths ≥ 500 g and neonatal deaths in 7 d PIH not defined | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.69 | 0.78 | 3.64
Derom, Leroy, Vlietinck, et al., 2006 #51560 | Geographical location: East Flanders, Belgium Study dates: 1964-2002 Size of population (no. of patients): 6208 twins, 170 triplets Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Included in provincial twin/triplet registry Exclusion criteria:; - Selective reduction; - Unknown mode of conception after 1985 | Definition(s) of outcome(s): Zygosity of multiple gestation Chorionicity of multiple gestation | 1) Monoyzygous vs dizygous twins, ovulation induction vs spontaneous: | | | | Comments: Not adjusted for birth year or maternal age Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Derom, Leroy, Vlietinck, et al., 2006 #51560 | Geographical location: East Flanders, Belgium Study dates: 1964-2002 Size of population (no. of patients): 6208 twins, 170 triplets Study type: Cohort | | Definition(s) of outcome(s): Zygosity of multiple gestation Chorionicity of multiple gestation | | Mono | Di | Total
Derom, Leroy, Vlietinck, et al., 2006 #51560 | Geographical location: East Flanders, Belgium Study dates: 1964-2002 Size of population (no. of patients): 6208 twins, 170 triplets Study type: Cohort | | Definition(s) of outcome(s): Zygosity of multiple gestation Chorionicity of multiple gestation | Induction | 57 | 704 | 761
Derom, Leroy, Vlietinck, et al., 2006 #51560 | Geographical location: East Flanders, Belgium Study dates: 1964-2002 Size of population (no. of patients): 6208 twins, 170 triplets Study type: Cohort | | Definition(s) of outcome(s): Zygosity of multiple gestation Chorionicity of multiple gestation | Spontaneous | 2072 | 2529 | 4601
Derom, Leroy, Vlietinck, et al., 2006 #51560 | Geographical location: East Flanders, Belgium Study dates: 1964-2002 Size of population (no. of patients): 6208 twins, 170 triplets Study type: Cohort | | Definition(s) of outcome(s): Zygosity of multiple gestation Chorionicity of multiple gestation | Total | 2129 | 3233 | 5362
Derom, Leroy, Vlietinck, et al., 2006 #51560 | Geographical location: East Flanders, Belgium Study dates: 1964-2002 Size of population (no. of patients): 6208 twins, 170 triplets Study type: Cohort | | Definition(s) of outcome(s): Zygosity of multiple gestation Chorionicity of multiple gestation | | Value | Lower 95% CI | Upper 95% CI
Derom, Leroy, Vlietinck, et al., 2006 #51560 | Geographical location: East Flanders, Belgium Study dates: 1964-2002 Size of population (no. of patients): 6208 twins, 170 triplets Study type: Cohort | | Definition(s) of outcome(s): Zygosity of multiple gestation Chorionicity of multiple gestation | Rel risk | 0.17 | 0.13 | 0.21
Derom, Leroy, Vlietinck, et al., 2006 #51560 | Geographical location: East Flanders, Belgium Study dates: 1964-2002 Size of population (no. of patients): 6208 twins, 170 triplets Study type: Cohort | | Definition(s) of outcome(s): Zygosity of multiple gestation Chorionicity of multiple gestation | 2) Monozygous vs dizygous, ART vs spontaneous:
Derom, Leroy, Vlietinck, et al., 2006 #51560 | Geographical location: East Flanders, Belgium Study dates: 1964-2002 Size of population (no. of patients): 6208 twins, 170 triplets Study type: Cohort | | Definition(s) of outcome(s): Zygosity of multiple gestation Chorionicity of multiple gestation | | Mono | Di | Total
Derom, Leroy, Vlietinck, et al., 2006 #51560 | Geographical location: East Flanders, Belgium Study dates: 1964-2002 Size of population (no. of patients): 6208 twins, 170 triplets Study type: Cohort | | Definition(s) of outcome(s): Zygosity of multiple gestation Chorionicity of multiple gestation | ART | 17 | 738 | 755
Derom, Leroy, Vlietinck, et al., 2006 #51560 | Geographical location: East Flanders, Belgium Study dates: 1964-2002 Size of population (no. of patients): 6208 twins, 170 triplets Study type: Cohort | | Definition(s) of outcome(s): Zygosity of multiple gestation Chorionicity of multiple gestation | Spontaneous | 2072 | 2529 | 4601
Derom, Leroy, Vlietinck, et al., 2006 #51560 | Geographical location: East Flanders, Belgium Study dates: 1964-2002 Size of population (no. of patients): 6208 twins, 170 triplets Study type: Cohort | | Definition(s) of outcome(s): Zygosity of multiple gestation Chorionicity of multiple gestation | Total | 2089 | 3267 | 5356
Derom, Leroy, Vlietinck, et al., 2006 #51560 | Geographical location: East Flanders, Belgium Study dates: 1964-2002 Size of population (no. of patients): 6208 twins, 170 triplets Study type: Cohort | | Definition(s) of outcome(s): Zygosity of multiple gestation Chorionicity of multiple gestation | | Value | Lower 95% CI | Upper 95% CI
Derom, Leroy, Vlietinck, et al., 2006 #51560 | Geographical location: East Flanders, Belgium Study dates: 1964-2002 Size of population (no. of patients): 6208 twins, 170 triplets Study type: Cohort | | Definition(s) of outcome(s): Zygosity of multiple gestation Chorionicity of multiple gestation | Rel risk | 0.05 | 0.03 | 0.08
3) Proportion of monozygous twins among different infertility treatments highest for clomiphene citrate alone (12% vs 3.6%).
Dokras, Baredziak, Blaine, et al., 2006 #51610 | Geographical location: Iowa City, Iowa Study dates: Jan 1995–Apr 2005 Size of population (no. of patients): 1293 Study type: Cohort | Age: Mean age 31 across all 4 Race/ethnicity (n [%]): White non-Hispanic: 94% Diagnoses (n [%]): PCOS more common (> 27% vs. < 7%) in women with BMI ≥ 30, unexplained infertility less common (< 6% vs. 10–12%) Inclusion criteria:; - Age < 38 years; - 1^st^ fresh IVF cycle; Exclusion criteria:; - Day 2 transfer cycles; - Cryopreserved embryo transfers; - Donor oocyte cycles; - GIFT/ZIFT | Definition(s) of outcome(s): Preeclampsia Gestational diabetes Cesarean section | 1) Trend for increasing rates of preeclampsia, gestational diabetes, preterm birth, cesarean section with increasing BMI, but insufficient power to show significant risk except for comparison of extremes (BMI < 25 vs BMI ≥ 40). | | | | Comments:; - Obstetric outcomes assessed by patient self-report; - Single center; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Dor, Lerner-Geva, Rabinovici, et al., 2002 #2860 | Geographical location: Israel Study dates: Treated 1981-1992, cases identified through December 1996 Size of population (no. of patients): 5026 Study type: Cohort | Age: Mean (SD): at treatment: 34.0 (6.4); at follow-up 37.5 (7.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Treated with IVF at sites during study time period; - at least one cycle; Exclusion criteria: NR | Definition(s) of outcome(s): Cancer cases reported to Israel National Cancer Registry | 1) Standardized Incidence Ratios: | | | | Comments:; - Subgroup analysis (by cause of infertility, # cycles) only done in 1524 subjects; - ?Peritoneal cancer should be analyzed as ovary; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining clinical outcomes: + Use of validated method for ascertaining exposure: + Adequate follow-up period: - Completeness of follow-up: - (NR) Analysis (multivariate adjustments) and reporting of results: +
Dor, Lerner-Geva, Rabinovici, et al., 2002 #2860 | Geographical location: Israel Study dates: Treated 1981-1992, cases identified through December 1996 Size of population (no. of patients): 5026 Study type: Cohort | | Definition(s) of outcome(s): Cancer cases reported to Israel National Cancer Registry | | SIR | 95% CI
Dor, Lerner-Geva, Rabinovici, et al., 2002 #2860 | Geographical location: Israel Study dates: Treated 1981-1992, cases identified through December 1996 Size of population (no. of patients): 5026 Study type: Cohort | | Definition(s) of outcome(s): Cancer cases reported to Israel National Cancer Registry | All cancers | 0.76 | 0.5,1.1
Dor, Lerner-Geva, Rabinovici, et al., 2002 #2860 | Geographical location: Israel Study dates: Treated 1981-1992, cases identified through December 1996 Size of population (no. of patients): 5026 Study type: Cohort | | Definition(s) of outcome(s): Cancer cases reported to Israel National Cancer Registry | Breast | 0.69 | 0.46,1.66
Dor, Lerner-Geva, Rabinovici, et al., 2002 #2860 | Geographical location: Israel Study dates: Treated 1981-1992, cases identified through December 1996 Size of population (no. of patients): 5026 Study type: Cohort | | Definition(s) of outcome(s): Cancer cases reported to Israel National Cancer Registry | Ovary | 0.57 | 0.01,3.2
Dor, Lerner-Geva, Rabinovici, et al., 2002 #2860 | Geographical location: Israel Study dates: Treated 1981-1992, cases identified through December 1996 Size of population (no. of patients): 5026 Study type: Cohort | | Definition(s) of outcome(s): Cancer cases reported to Israel National Cancer Registry | Cervix | 0.58 | 0.01,3.22
Dor, Lerner-Geva, Rabinovici, et al., 2002 #2860 | Geographical location: Israel Study dates: Treated 1981-1992, cases identified through December 1996 Size of population (no. of patients): 5026 Study type: Cohort | | Definition(s) of outcome(s): Cancer cases reported to Israel National Cancer Registry | Endometrium | 2.25 | 0.25,8.1
Dor, Lerner-Geva, Rabinovici, et al., 2002 #2860 | Geographical location: Israel Study dates: Treated 1981-1992, cases identified through December 1996 Size of population (no. of patients): 5026 Study type: Cohort | | Definition(s) of outcome(s): Cancer cases reported to Israel National Cancer Registry | Other* | 0.78 | 0.4,1.36)
Dor, Lerner-Geva, Rabinovici, et al., 2002 #2860 | Geographical location: Israel Study dates: Treated 1981-1992, cases identified through December 1996 Size of population (no. of patients): 5026 Study type: Cohort | | Definition(s) of outcome(s): Cancer cases reported to Israel National Cancer Registry | *Colon cancer (3 cases); melanoma (3 cases); and 1 case each of tongue cancer, thyroid cancer, stomach cancer, leukemia, lymphoma, and cancer of the peritoneum.
2) Total 27 cancers diagnosed 1 year or more after treatment. 13 diagnosed within 1 year, not included in analysis.
Doria-Rose, Lou Biggs, and Weiss, 2005 #39770 | Geographical location: Seattle, WA Study dates: 1977 - 1983 Size of population: 329 cases, 675 controls Study type: Case-control | Age: NR Race/ethnicity (n [%]): 100% White Diagnoses (n [%]): NR Inclusion criteria: All cases of germ cell testicular CA dx'd 1977 - 1983 in western WA. Controls by random digit dialing. Only white men 20 – 69yo who spoke English and had telephone Exclusion criteria: Non-white, unable to locate, dead, refusal | Definition(s) of outcome(s): Testicular germ cell CA | 1) No. of children fathered as risk factor for CA: | | | | Comment: Recall bias Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: - Appropriateness of the control population: + Verification that the control is free of cancer: - (not stated specifically) Comparability of cases and controls with respect to potential confounders: + Validated dietary assessment method: n/a Appropriateness of statistical analyses: +
Doria-Rose, Lou Biggs, and Weiss, 2005 #39770 | Geographical location: Seattle, WA Study dates: 1977 - 1983 Size of population: 329 cases, 675 controls Study type: Case-control | | Definition(s) of outcome(s): Testicular germ cell CA | | CA | ctrl | Total
Doria-Rose, Lou Biggs, and Weiss, 2005 #39770 | Geographical location: Seattle, WA Study dates: 1977 - 1983 Size of population: 329 cases, 675 controls Study type: Case-control | | Definition(s) of outcome(s): Testicular germ cell CA | 0 | 173 | 330 | 503
Doria-Rose, Lou Biggs, and Weiss, 2005 #39770 | Geographical location: Seattle, WA Study dates: 1977 - 1983 Size of population: 329 cases, 675 controls Study type: Case-control | | Definition(s) of outcome(s): Testicular germ cell CA | any | 156 | 342 | 498
Doria-Rose, Lou Biggs, and Weiss, 2005 #39770 | Geographical location: Seattle, WA Study dates: 1977 - 1983 Size of population: 329 cases, 675 controls Study type: Case-control | | Definition(s) of outcome(s): Testicular germ cell CA | Total | 329 | 672 | 1001
Doria-Rose, Lou Biggs, and Weiss, 2005 #39770 | Geographical location: Seattle, WA Study dates: 1977 - 1983 Size of population: 329 cases, 675 controls Study type: Case-control | | Definition(s) of outcome(s): Testicular germ cell CA | | Value | Lower 95% CI | Upper 95% CI
Doria-Rose, Lou Biggs, and Weiss, 2005 #39770 | Geographical location: Seattle, WA Study dates: 1977 - 1983 Size of population: 329 cases, 675 controls Study type: Case-control | | Definition(s) of outcome(s): Testicular germ cell CA | Odds rat | 1.15 | 0.88 | 1.50
Doria-Rose, Lou Biggs, and Weiss, 2005 #39770 | Geographical location: Seattle, WA Study dates: 1977 - 1983 Size of population: 329 cases, 675 controls Study type: Case-control | | Definition(s) of outcome(s): Testicular germ cell CA | 2) Infertility as risk factor for CA:
Doria-Rose, Lou Biggs, and Weiss, 2005 #39770 | Geographical location: Seattle, WA Study dates: 1977 - 1983 Size of population: 329 cases, 675 controls Study type: Case-control | | Definition(s) of outcome(s): Testicular germ cell CA | | CA | ctrl | Total
Doria-Rose, Lou Biggs, and Weiss, 2005 #39770 | Geographical location: Seattle, WA Study dates: 1977 - 1983 Size of population: 329 cases, 675 controls Study type: Case-control | | Definition(s) of outcome(s): Testicular germ cell CA | Infert | 12 | 10 | 22
Doria-Rose, Lou Biggs, and Weiss, 2005 #39770 | Geographical location: Seattle, WA Study dates: 1977 - 1983 Size of population: 329 cases, 675 controls Study type: Case-control | | Definition(s) of outcome(s): Testicular germ cell CA | No infert | 317 | 662 | 979
Doria-Rose, Lou Biggs, and Weiss, 2005 #39770 | Geographical location: Seattle, WA Study dates: 1977 - 1983 Size of population: 329 cases, 675 controls Study type: Case-control | | Definition(s) of outcome(s): Testicular germ cell CA | Total | 329 | 672 | 1001
Doria-Rose, Lou Biggs, and Weiss, 2005 #39770 | Geographical location: Seattle, WA Study dates: 1977 - 1983 Size of population: 329 cases, 675 controls Study type: Case-control | | Definition(s) of outcome(s): Testicular germ cell CA | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 2.51 | 1.07 | 5.86
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | Age: Mean (SD): IVF/ICSI: 32.0 (5.2); spontaneous 27.8 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF—successful pregnancy from 2 practitiioners; - Spontaneous—ob patients followed by same practitioners; Exclusion criteria: NR | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | 1) “Neuro-orthopedic” malformations, crude relative risk: | | | | Comments: Significantly more multiples, lower birthweight, primiparous, c-sections in IVF/ICSI gropu Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining clinical outcomes: + Use of validated method for ascertaining exposure: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | | Out + | Out - | Total
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | IVF/ICSI + | 7 | 773 | 780
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | IVF - | 7 | 2161 | 2168
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | Total | 14 | 2934 | 2948
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | | Value | Lower 95% CI | Upper 95% CI
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | Rel risk | 2.78 | 0.98 | 7.90
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | Risk estimate reduced after adjustment for low birthweight, multiple gestation, primiparity (although apparently not adjusted for maternal age)
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | 2) All malformations, crude relative risk:
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | | Out + | Out - | Total
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | Exp + | 19 | 761 | 780
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | Exp - | 23 | 2145 | 2168
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | Total | 42 | 2906 | 2948
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | | Value | Lower 95% CI | Upper 95% CI
El Hage, Ghanem, Safi, et al., 2006 #51680 | Geographical location: Beirut, Lebanon Study dates: Jan 1996–Dec 2001 Size of population (no. of patients): 780 IVF/ICSI birth (89.6% ICSI) 2168 spontaneous Study type: Cohort | | Definition(s) of outcome(s): “Neuro-orthopedic” malformations—not specifically defined, includes range of diagnoses from neural tube defects to club feet not usually associated with syndrome | Rel risk | 2.30 | 1.26 | 4.19
Adjusted estimates not reported
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | Geographical location: Boston, MA Study dates: NR Size of population: 249 mothers of 128 singletons, 111 twins, 10 triplets Study type: Cohort Sent questionnaires to subjects who conceived by ART. Matched singleton mothers to multiple moms by children's yr of birth, maternal age, and parity. | Age: Mean (SD): Mothers: 35 (4) Children: 22 mo (8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Subjects identified through 2 infertility clinics; - Conceived by ART; - Children ≥ 12 mo old; - Residing in New England; - Treated in MA; Exclusion criteria:; - Children > 48 mo old | Definition(s) of outcome(s): Assessments of:; - Meeting material needs (higher scores = increased unmet material needs); - Social stigma; - Overall quality of life (Ferrans and Powers Quality of Life Index); - Marital satisfaction (Kansas Marital Satisfaction Scale); - Stress (Cohen Perceived Stress Scale); - Depression (Centers for Epidemiological Study-Depression Scale); - Children with health or developmental problems | Data presented as % prevalence; calculated from %s | | | | Comments:; - Response rate 64%; - Higher for multiples (77% vs 52%); Quality assessment: For cohort study: Unbiased selection of the cohort (prospective recruitment of subjects): Large sample size: Adequate description of the cohort: Use of validated method for ascertaining exposure: Use of validated method for ascertaining clinical outcomes: Adequate follow-up period: Completeness of follow-up: Analysis (multivariate adjustments) and reporting of results:
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | 1) Difficulty meeting material needs:
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Mat needs + | Mat needs - | Total
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Twin | 20 | 91 | 111
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Single | 3 | 125 | 128
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Total | 23 | 216 | 239
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Value | Lower 95% CI | Upper 95% CI
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Odds rat | 9.16 | 2.64 | 31.75
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Mat needs + | Mat needs - | Total
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Triplet | 3 | 7 | 10
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Single | 3 | 125 | 128
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Total | 6 | 132 | 138
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Value | Lower 95% CI | Upper 95% CI
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Odds rat | 17.86 | 3.04 | 105.06
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | 2) Lower quality of life:
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Low QOL + | Low QOL - | Total
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Twin | 13 | 98 | 111
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Single | 6 | 122 | 128
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Total | 19 | 220 | 239
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Value | Lower 95% CI | Upper 95% CI
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Odds rat | 2.70 | 0.99 | 7.36
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Low QOL + | Low QOL - | Total
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Triplet | 2 | 8 | 10
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Single | 6 | 122 | 128
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Total | 8 | 130 | 138
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Value | Lower 95% CI | Upper 95% CI
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Odds rat | 5.08 | 0.88 | 29.34
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | 3) Social stigma:
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Stigma + | Stigma - | Total
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Twin | 20 | 91 | 111
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Single | 10 | 118 | 128
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Total | 30 | 209 | 239
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Value | Lower 95% CI | Upper 95% CI
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Odds rat | 2.59 | 1.16 | 5.81
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Stigma + | Stigma - | Total
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Triplet | 2 | 8 | 10
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Single | 10 | 118 | 128
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Total | 12 | 126 | 138
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Value | Lower 95% CI | Upper 95% CI
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Odds rat | 2.95 | 0.55 | 15.81
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | 4) Maternal depression:
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Depress + | Depress - | Total
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Twin | 25 | 86 | 111
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Single | 20 | 108 | 128
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Total | 45 | 194 | 239
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Value | Lower 95% CI | Upper 95% CI
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Odds rat | 1.57 | 0.82 | 3.02
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Depress + | Depress - | Total
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Triplet | 4 | 6 | 10
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Single | 20 | 108 | 128
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Total | 24 | 114 | 138
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Value | Lower 95% CI | Upper 95% CI
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Odds rat | 3.60 | 0.93 | 13.92
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | 5) Maternal stress:
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Stress + | Stress - | Total
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Twin | 8 | 103 | 111
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Single | 9 | 119 | 128
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Total | 17 | 222 | 239
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Value | Lower 95% CI | Upper 95% CI
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Odds rat | 1.03 | 0.38 | 2.76
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Stress + | Stress - | Total
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Triplet | 1 | 9 | 10
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Single | 9 | 119 | 128
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Total | 10 | 128 | 138
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Value | Lower 95% CI | Upper 95% CI
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Odds rat | 1.47 | 0.17 | 12.92
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | 6) Lower marital satisfaction
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Low mar satis + | Low mar satis - | Total
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Twin | 13 | 98 | 111
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Single | 10 | 118 | 128
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Total | 23 | 216 | 239
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Value | Lower 95% CI | Upper 95% CI
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Odds rat | 1.57 | 0.66 | 3.72
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Low mar satis + | Low mar satis - | Total
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Triplet | 2 | 8 | 10
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Single | 10 | 118 | 128
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | Total | 12 | 126 | 138
Ellison, Hotamisligil, Lee, et al., 2005 #40420 | | | | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 2.95 | 0.55 | 15.81
Erez, Vardi, Hallak, et al., 2006 #51770 | Geographical location: Beer Sheba, Israel Study dates: 1988-2002 Size of population (no. of patients): 2628 Study type: Case-control | Age: IVF: 31 Spontaneous: 29 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Twin pregnancy; - Delivered in hospital; - > 22 weeks; Exclusion criteria: < 3 prenatal visits | Definition(s) of outcome(s): Mild GH was defined as diastolic blood pressure 590 mmHg and 5110 mmHg and systolic blood pressure 5140 mmHg and 5160 mmHg. Severe GH was defined as diastolic blood pressure 5110 mmHg and systolic blood pressure 5160 mmHg. Preeclampsia was defined as elevated blood pressure and proteinuria. The severity of preeclampsia was defined according to the severity of hypertension and any one of the following: proteinuria in nephritic range defined as þ3 proteinuria by dipstick or more than 3 g protein in the urine in 24 hours collection, thrombocytopenia 4100 000, elevated liver enzymes, persistent headache and blurred vision | 1) IVF vs. none, mild and severe preeclampsia combined: | | | | Comments: None Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: - Appropriateness of the control population: + Comparability of cases and controls with respect to potential confounders: + Appropriateness of statistical analyses: +
Erez, Vardi, Hallak, et al., 2006 #51770 | Geographical location: Beer Sheba, Israel Study dates: 1988-2002 Size of population (no. of patients): 2628 Study type: Case-control | Age: IVF: 31 Spontaneous: 29 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Twin pregnancy; - Delivered in hospital; - > 22 weeks; Exclusion criteria: < 3 prenatal visits | | | Out + | Out - | Total
Erez, Vardi, Hallak, et al., 2006 #51770 | Geographical location: Beer Sheba, Israel Study dates: 1988-2002 Size of population (no. of patients): 2628 Study type: Case-control | Age: IVF: 31 Spontaneous: 29 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Twin pregnancy; - Delivered in hospital; - > 22 weeks; Exclusion criteria: < 3 prenatal visits | | Exp + | 51 | 193 | 244
Erez, Vardi, Hallak, et al., 2006 #51770 | Geographical location: Beer Sheba, Israel Study dates: 1988-2002 Size of population (no. of patients): 2628 Study type: Case-control | Age: IVF: 31 Spontaneous: 29 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Twin pregnancy; - Delivered in hospital; - > 22 weeks; Exclusion criteria: < 3 prenatal visits | | Exp - | 241 | 2143 | 2384
Erez, Vardi, Hallak, et al., 2006 #51770 | Geographical location: Beer Sheba, Israel Study dates: 1988-2002 Size of population (no. of patients): 2628 Study type: Case-control | Age: IVF: 31 Spontaneous: 29 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Twin pregnancy; - Delivered in hospital; - > 22 weeks; Exclusion criteria: < 3 prenatal visits | | Total | 292 | 2336 | 2628
Erez, Vardi, Hallak, et al., 2006 #51770 | Geographical location: Beer Sheba, Israel Study dates: 1988-2002 Size of population (no. of patients): 2628 Study type: Case-control | Age: IVF: 31 Spontaneous: 29 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Twin pregnancy; - Delivered in hospital; - > 22 weeks; Exclusion criteria: < 3 prenatal visits | | | Value | Lower 95% CI | Upper 95% CI
Erez, Vardi, Hallak, et al., 2006 #51770 | Geographical location: Beer Sheba, Israel Study dates: 1988-2002 Size of population (no. of patients): 2628 Study type: Case-control | Age: IVF: 31 Spontaneous: 29 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Twin pregnancy; - Delivered in hospital; - > 22 weeks; Exclusion criteria: < 3 prenatal visits | | Odds rat | 2.35 | 1.68 | 3.29
2) After adjusting for chronic HTN, diabetes, primiparity, twin discordance, and maternal age, OR for IVF 1.08 (0.74, 1.39)
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | 1) Odds ratios, any hospitalization: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | | OR | 95% CI
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | All children
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Crude | 1.74 | 1.67,1.82
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Adjusted* | 1.84 | 1.76,1.92
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | All term births
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Crude | 1.25 | 1.19,1.32
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Adjusted* | 1.34 | 1.27,1.41
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Singleton
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Adjusted* | 1.40 | 1.32,1.48
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Twins
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Adjusted* | 1.17 | 1.07,1.27
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | *Adjusted for maternal age, parity, smoking
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | 2) Adjusted*odds ratios, specific diagnoses:
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | | OR | 95% CI
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Cerebral palsy | 1.69 | 1.06,2.68
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Epilepsy | 1.54 | 1.10,2.15
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Mental retardation | 0.94 | 0.39,2.27
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Developmental issue | 1.35 | 0.86,2.11
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | All neurologic dx | 1.51 | 1.18,1.93
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Accident | 1.06 | 0.95,1.17
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Tumors | 1.57 | 1.16,2.13
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Asthma (> age 1) | 1.37 | 1.20,1.56
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Any infection | 1.36 | 1.29,1.44
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | Congenital malformation | 1.84 | 1.67,2.03
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | *Adjusted for maternal age, parity, smoking, year of birth
Ericson, Nygren, Olausson, et al., 2002 #2440 | Geographical location: Sweden Study dates: Born 1984-1997 Size of population (no. of patients): 1,417,166 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Live birth in Sweden; - Exposure: IVF (from registry); Exclusion criteria: NR | Definition(s) of outcome(s): Hospitalization (any cause) | 3) ORs increase with duration of infertility, decrease with child age (but still significant through age 6)
4) Based on Cancer Registry, no increased cancer risk—RR 0.88, 95% CI 0.44,1.58
Farr, Schieve, and Jamieson, 2007 #70990 | Geographical location: US (SART registry) Study dates: 1999-2002 Size of population (no. of patients): 148,494 Study type: Cohort All pregnancies in SART registry | Age: Range: < 33 48,804 (32.9%) 33–34 22,887 (15.4%) 35–37 32,369 (21.8%) 38–40 24,284 (16.4%) 41–42 9,642 (6.5%) > 42 10,508 (7.1%) Race/ethnicity (n [%]): White 72,980 (49.15) Asian* 4,473 (3.01) White Hispanic 4,403 (2.97) African American* 3,509 (2.36) Other race 116 (0.08) Missing 63,013(42.43) Diagnoses (n [%]): Not reported in detail Inclusion criteria: NR Exclusion criteria:; - Treatments canceled prior to egg retrieval, treatments with unsuccessful embryo transfers, and treatments using zygote intrafallopian transfer, gamete intrafallopian transfer, or zygote or gamete intrafallopian transfer in combination with IVF with transcervical embryo transfer, use of both donor and patient oocytes or embryos, both freshly fertilized and frozen embryos, a gestational carrier, or those missing data on whether the treatment resulted in pregnancy; - Missing or conflicting values for dates of oocyte retrieval, embryo transfer, ultrasound observation of fetal heartbeat, or pregnancy outcome and pregnancies with missing data on potential confounders. | Definition(s) of outcome(s): Loss of pregnancy | 1) Loss after 7 weeks, single heart beat vs. 2 or more heart beats: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Farr, Schieve, and Jamieson, 2007 #70990 | Geographical location: US (SART registry) Study dates: 1999-2002 Size of population (no. of patients): 148,494 Study type: Cohort All pregnancies in SART registry | | Definition(s) of outcome(s): Loss of pregnancy | | Loss+ | Loss - | Total
Farr, Schieve, and Jamieson, 2007 #70990 | Geographical location: US (SART registry) Study dates: 1999-2002 Size of population (no. of patients): 148,494 Study type: Cohort All pregnancies in SART registry | | Definition(s) of outcome(s): Loss of pregnancy | Two or more | 2176 | 43015 | 45191
Farr, Schieve, and Jamieson, 2007 #70990 | Geographical location: US (SART registry) Study dates: 1999-2002 Size of population (no. of patients): 148,494 Study type: Cohort All pregnancies in SART registry | | Definition(s) of outcome(s): Loss of pregnancy | Single | 9875 | 62664 | 72539
Farr, Schieve, and Jamieson, 2007 #70990 | Geographical location: US (SART registry) Study dates: 1999-2002 Size of population (no. of patients): 148,494 Study type: Cohort All pregnancies in SART registry | | Definition(s) of outcome(s): Loss of pregnancy | Total | 12051 | 105679 | 117730
Farr, Schieve, and Jamieson, 2007 #70990 | Geographical location: US (SART registry) Study dates: 1999-2002 Size of population (no. of patients): 148,494 Study type: Cohort All pregnancies in SART registry | | Definition(s) of outcome(s): Loss of pregnancy | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.35 | 0.34 | 0.37
Fisher, Hammarberg, and Baker, 2005 #40270 | Geographical location: Melbourne, Australia Study dates: Jul 2000–Aug 2002 Size of population: 745 Study type: Cohort (retrospective) Systematic audit of consecutive medical records of mother-infant dyads admitted to mother/baby unit. Mode of conception spontaneous, OI & AI (ovulation induction & artificial insemination), or IVF | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | 1) EPDS score > 12 on day 1: | | | | Comments: No mention that abstractors were blinded to mode of conception Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for genomic test: Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | | Day 1 > 12 | Day 1 ≤ 12 | Total
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | OI/AI | 7 | 5 | 12
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | Spont | 322 | 356 | 678
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | Total | 329 | 361 | 690
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | | Value | Lower 95% CI | Upper 95% CI
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | Odds rat | 1.55 | 0.49 | 4.93
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | | Day 1 > 12 | Day 1 ≤ 12 | Total
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | IVF | 22 | 23 | 45
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | Spont | 322 | 356 | 678
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | Total | 344 | 379 | 723
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | | Value | Lower 95% CI | Upper 95% CI
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | Odds rat | 1.06 | 0.58 | 1.93
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | 2) EPDS score > 12 on day 5:
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | | Day 5 > 12 | Day 5 ≤ 12 | Total
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | OI/AI | 3 | 9 | 12
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | Spont | 102 | 551 | 653
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | Total | 105 | 560 | 665
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | | Value | Lower 95% CI | Upper 95% CI
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | Odds rat | 1.80 | 0.48 | 6.77
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | | Day 5 > 12 | Day 5 ≤ 12 | Total
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | IVF | 6 | 38 | 44
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | Spont | 102 | 551 | 653
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | Total | 108 | 589 | 697
Fisher, Hammarberg, and Baker, 2005 #40270 | | Age: Mean (SD): Spontaneous: 33.09 (4.01) OI & AI: 33.45 (3.11) IVF: 35.88 (3.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive Exclusion criteria: NR | Definition(s) of outcome(s): Edinburgh Postnatal Depression Scale (EPDS) | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 0.85 | 0.35 | 2.07
Gauthier, Paoletti, Clavel-Chapelon, et al., 2004 #11240 | Geographical location: France Study dates: Enrolled between June 1990–Nov 1991; follow-up through June 2000 Size of population (no. of patients): Infertile: 6602 No infertility: 85,948 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Breast cancer cases, validated through medical records when possible | 1) Adjusted hazard ratios (proportional hazards models): Any treatment for infertility: 0.95 (0.82, 1.11) Treated with drugs/IVF: 0.94 (0.78, 1.12) No association with specific drugs, duration of treatment, or age at treatment | | | | Comments:; - Infertilty status, treatment by selfreport; - 9.7 years mean follow-up—longer than most cohorts in this population; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining exposure: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | Age: Mean: ICSI: 32.6 Control: 32.5 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: ICSI pregnancies that had 18–24 wk uterine artery Doppler studies. Controls selected from database, also only routine exams, matched for age, parity, plurality. Exclusion criteria: Fetuses with malformations or other indications besides screening (suspected anomaly, FGR) | Definition(s) of outcome(s): “High-risk” = CHtn, DM, BMI > 27, nullipar ≥ 35yo, multipar with h/o FGR, preex, abruption, or IUFD Discordance > 20% SGA < 10%ile for German population Preex = repeated BP ≥ 140/90 + proteinuria > 500 mg/day | 1) C/S in singletons: | | | | Comments:; - No mention of how controls conceived - IVF? OI? Spont?; - All were di/di twins; - Similar rates of nulliparity and AMA in both groups; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: - Appropriateness of the control population: - Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: - Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | | | | C/S+ | C/S- | Total
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | | | ICSI | 40 | 74 | 114
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | | | ctrl | 35 | 79 | 114
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | | | Total | 75 | 153 | 228
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | | | | Value | Lower 95% CI | Upper 95% CI
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | | | Odds rat | 1.22 | 0.70 | 2.12
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | | | 2) C/S in twins:
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | | | | C/S+ | C/S- | Total
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | | | ICSI | 25 | 7 | 32
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | | | ctrl | 21 | 11 | 32
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | | | Total | 46 | 18 | 64
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | | | | Value | Lower 95% CI | Upper 95% CI
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | | | Odds rat | 1.87 | 0.62 | 5.68
Geipel, Ludwig, Germer, et al., 2001 #4920 | Geographical location: Lubeck, Germany Study dates: Jan 1995–Jul 1999 Size of population: ICSI: 114 singletons, 32 twins. Equal numbers of controls. Study type: Case-control | | | No difference in any other outcome: SGA, preex, abruption, PPROM, PTD.
No significant difference in any outcome by Doppler result, or among high-risk or low-risk patients.
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | Age: Median (IQR): Natural: 39 (27–31) IVF single: 34 (31–37) IVF multiple: 32 (29–35) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF group:; - Residence in UK; - At least 18 wks pregnant; Natural conception group:; - Stable relationship; - Speak English; - Age ≥ 24 yrs; - At least 18 wks pregnant; - No med/surg treatment for infertility in current pregnancy; - Nulliparous; - Singleton pregnancy; Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight Days premature Newborn length of hospitalization NICU admission Newborn medical complications Psychiatric/emotional well-being @ 1 yr postpartum Parenting stress index @ 1 yr postpartum | 1) All data except for NICU admission & newborn complications are reported as continuous variables, therefore, unable to calculate RR from these data. | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: +/- Adequate description of the cohort: + Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | | Natural concept single | IVF single | IVF multiple
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | Mean BWT (kg) | 3.37 | 3.31 | 2.15
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | Median days preterm | 1.0 | 3.0 | 22.5
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | Median days baby in hospital | 3.5 | 4.0 | 7.0
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | Parent distress | 24 | 24.83 | 28
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | Parent-child dysfunctional interaction | 14 | 14 | 16
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | Difficult child | 0 | 9 | 24
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | Defensive responding | 15 | 14 | 15
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | 2) NICU admission for singletons only:
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | | NICU admit + | NICU admit - | Total
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | Sing IVF | 6 | 89 | 95
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | Sing natural | 6 | 123 | 129
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | Total | 12 | 212 | 224
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | Rel risk | 1.36 | 0.45 | 4.08
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | 3) Newborn medical complications:
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | | Med compl + | Med compl - | Total
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | Sing IVF | 26 | 69 | 95
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | Sing natural | 22 | 107 | 129
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | Total | 48 | 176 | 224
Glazebrook, Sheard, Cox, et al., 2004 #13650 | Geographical location: United Kingdom Study dates: NR Size of population: 260 (129 natural conceptions, 95 IVF singletons, 36 IVF multiples) Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.60 | 0.97 | 2.65
Goody, Rice, Boivin, et al., 2005 #40820 | Geographical location: Cardiff, UK Study dates: 1996 Size of population: 101 families with ART twins, 1,073 naturally conceived control DZ twin pairs Study type: Cohort (retrospective) Questionnaire mailed to families of school-age twins | Age: Mean (SD): NC 28.43, ART 29.61 Race/ethnicity (n [%]): 93% British in both grps Small numbers of Bangladeshi/Indian/Pakistani, African/Caribbean, Jewish, Arab, SE Asian. Diagnoses (n [%]): NR Inclusion criteria: School-aged twins in 9 health districts in Greater Manchester and Lancashire, UK who completed & returned package of questionnaires. Only twins assessed to be dizygotic by questionnaire and ‘an algorithm based on previous work’ were included. Exclusion criteria: Failure to indicate whether or not ART had been used | Definition(s) of outcome(s): Pregnancy risk score calculated based on # of cigarettes smoked during pregnancy, admission to hosp bc of Htn & edema, VB. Delivery risk included emergency C/S, operative vag del, labor <3h or >36h. Modified DuPaul ADHD rating scale used to assess parent & teacher-assessed child psychopathology. Internalizing Sx - Rutter scales Antisocial behavior - conduct difficulties subscale of Rutter scales Family Environment - maternal report of Family Environment Scale Educational difficulties - mothers report | Data on C/S not presented. | | | | Comment:; - Response rate 73%; - 77% gave permission to contact teachers, 92% of teachers replied.; - Relied on parental reporting, not record review or standardized tests.; - No information of specific conception techniques.; - NC families had more siblings, were of lower social class, mothers more likely to have smoked during preg.; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Goody, Rice, Boivin, et al., 2005 #40820 | | | | No n given, just %
Goody, Rice, Boivin, et al., 2005 #40820 | | | | 1) Behind in reading:
Goody, Rice, Boivin, et al., 2005 #40820 | | | | | yes | no | Total
Goody, Rice, Boivin, et al., 2005 #40820 | | | | ART | 15 | 86 | 101
Goody, Rice, Boivin, et al., 2005 #40820 | | | | NC | 201 | 872 | 1073
Goody, Rice, Boivin, et al., 2005 #40820 | | | | Total | 216 | 958 | 1174
Goody, Rice, Boivin, et al., 2005 #40820 | | | | | Value | Lower 95% CI | Upper 95% CI
Goody, Rice, Boivin, et al., 2005 #40820 | | | | Odds rat | 0.76 | 0.43 | 1.34
Goody, Rice, Boivin, et al., 2005 #40820 | | | | 2) Learning difficulty:
Goody, Rice, Boivin, et al., 2005 #40820 | | | | | yes | no | Total
Goody, Rice, Boivin, et al., 2005 #40820 | | | | ART | 12 | 89 | 101
Goody, Rice, Boivin, et al., 2005 #40820 | | | | NC | 147 | 926 | 1073
Goody, Rice, Boivin, et al., 2005 #40820 | | | | Total | 159 | 1015 | 1174
Goody, Rice, Boivin, et al., 2005 #40820 | | | | | Value | Lower 95% CI | Upper 95% CI
Goody, Rice, Boivin, et al., 2005 #40820 | | | | Odds rat | 0.85 | 0.45 | 1.59
No parent- or teacher-rated measure of child psychopathology differed between grps except teacher-rated ADHD (continuous variable, higher in NC grp). When maternal smoking & demographics were controlled for, no difference found.
Gray and Wu, 2000 #7000 | Geographical location: Fishkill, NY and Burlington, VT Study dates: June 1989–July 1990 conducted study, reported pregnancies from 1980-1990 Size of population (no. of patients): 1572 women Study type: Cohort study | Age: ≤ 24 n=1001 25–29 n= 1277 30–34 n=573 ≥ 35 n=116 Race/ethnicity (n [%]): 92.8% white n = 1459 Diagnoses (n [%]): NR Inclusion criteria: Women, 15–44 yr old, work in manufacturing or non-manufacturing jobs or wives of male employees Exclusion criteria: s/p sterilization, hysterectomy, or husband s/p vasectomy | Definition(s) of outcome(s): Subfertility ≥ 1yr to conception Spontaneous abortion | 1) SAb among those with and without subfertility: | | | | Comments: Retrospective interviews, subject to significant recall bias, especially associated with poor outcome Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: - Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Gray and Wu, 2000 #7000 | | | Definition(s) of outcome(s): Subfertility ≥ 1yr to conception Spontaneous abortion | | SAb + | SAb - | Total
Gray and Wu, 2000 #7000 | | | Definition(s) of outcome(s): Subfertility ≥ 1yr to conception Spontaneous abortion | Subfert + | 67 | 225 | 292
Gray and Wu, 2000 #7000 | | | Definition(s) of outcome(s): Subfertility ≥ 1yr to conception Spontaneous abortion | Subfert - | 375 | 2592 | 2967
Gray and Wu, 2000 #7000 | | | Definition(s) of outcome(s): Subfertility ≥ 1yr to conception Spontaneous abortion | Total | 442 | 2817 | 3259
Gray and Wu, 2000 #7000 | | | Definition(s) of outcome(s): Subfertility ≥ 1yr to conception Spontaneous abortion | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.82 | 1.44 | 2.29
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | Geographical location: Perth, Australia Study dates: 1993 - 97 Size of population: 301 ICSI, 837 IVF, 4,000 naturally conceived Study type: Case-control All ICSI & IVF births in time period, compared to randomly selected naturally-conceived controls in same time period | Age: Mean (SD): ICSI 32.6 (4.0), IVF 34.1 (4.6), NC 28.2 (4.4) Race/ethnicity (n [%]): (ICSI IVF, NC): White 230 (96%), 639 (95%), 3,500 (88%) Aboriginal or Torres Strait Islander 1 (<1%), 3 (<1%), 280 (7%) Other 9 (4%), 34 (5%), 280 (7%) Diagnoses (n [%]): NR Inclusion criteria: Pregnancies >=20wks, terminations because of fetal anomalies (regardless of length of gestation) - included all those conceived by ICSI or IVF, and random sample of 4,000 non-ART controls. Data collected by Midwives' Notification System, which collects info on all infants delivered in western Australia Exclusion criteria: NR | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | 1) C/S, ICSI vs NC: | | | | Comments:; - ICSI, IVF more likely married or cohabiting, nullip, white, metropolitan than NC grp; - Same source of data and classification system for all grps. Data collected w/o reference to mode of conception; - No effect on findings when pregnancies terminated for birth defects were added to analysis; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: - (not matched for mat age, gest age) Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: - (see above) Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | C/S+ | C/S- | Total
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | ICSI | 95 | 206 | 301
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | NC | 816 | 3184 | 4000
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Total | 911 | 3390 | 4301
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | Value | Lower 95% CI | Upper 95% CI
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Odds rat | 1.80 | 1.39 | 2.32
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | 2) C/S, IVF vs NC:
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | C/S+ | C/S- | Total
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | IVF | 365 | 472 | 837
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | NC | 816 | 3184 | 4000
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Total | 1181 | 3656 | 4837
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | Value | Lower 95% CI | Upper 95% CI
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Odds rat | 3.02 | 2.58 | 3.53
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | 3) C/S, ICSI vs NC, singletons only:
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | C/S+ | C/S- | Total
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | ICSI | 48 | 138 | 186
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | NC | 776 | 3130 | 3906
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Total | 824 | 3268 | 4092
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | Value | Lower 95% CI | Upper 95% CI
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Odds rat | 1.40 | 1.00 | 1.97
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | 4) C/S, IVF vs NC, singletons only:
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | C/S+ | C/S- | Total
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | IVF | 183 | 344 | 527
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | NC | 776 | 3130 | 3906
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Total | 959 | 3474 | 4433
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | Value | Lower 95% CI | Upper 95% CI
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Odds rat | 2.15 | 1.76 | 2.61
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | 5) Birth defects overall, ICSI vs NC:
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | Malf+ | Malf- | Total
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | ICSI | 26 | 275 | 301
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | NC | 168 | 3832 | 4000
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Total | 194 | 4107 | 4301
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | Value | Lower 95% CI | Upper 95% CI
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Odds rat | 2.16 | 1.40 | 3.32
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | 6) Birth defects overall, IVF vs NC:
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | Malf+ | Malf- | Total
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | IVF | 75 | 762 | 837
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | NC | 168 | 3832 | 4000
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Total | 243 | 4594 | 4837
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | Value | Lower 95% CI | Upper 95% CI
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Odds rat | 2.25 | 1.69 | 2.98
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | 7) Birth defects, singletons only:
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | Malf+ | Malf- | Total
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | ICSI | 18 | 168 | 186
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | NC | 164 | 3742 | 3906
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Total | 182 | 3910 | 4092
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | Value | Lower 95% CI | Upper 95% CI
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Odds rat | 2.44 | 1.47 | 4.07
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | 8) Birth defects, singletons only:
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | Malf+ | Malf- | Total
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | IVF | 50 | 477 | 527
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | NC | 164 | 3742 | 3906
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Total | 214 | 4219 | 4433
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | | Value | Lower 95% CI | Upper 95% CI
Hansen, Kurincsuk, Bower, et al., 2002 #2520 | | | Definition(s) of outcome(s): Birth defect = abnormalities probably of prenatal origin Maj/minor by CDC method F/u period is 1yr | Odds rat | 2.39 | 1.72 | 3.33
Paper includes adjusted OR's for maternal age, parity, infant sex, correlation btw siblings.
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | Age: NR Race/ethnicity (n [%]): For infants: 80.9% whites, 19.1% non-whites Natural conception: 68.2% white ART: 95% white Diagnoses (n [%]): NR Inclusion criteria:; - All multiple live births during study dates with birthweight 401–1500 g, cared for in 1 of 3 Cincinnati NICUs, twins/triplets/quads; Exclusion criteria: NR | Definition(s) of outcome(s): Bronchopulmonary dysplasia (BPD) = supplemental oxygen at 36 wks postmenstrual age or discharge home on oxygen Death = death before NICU discharge or before 120 days of life Antenatal steroids = receipt with intent for pulmonary maturity | 1) Risk of BPD: | | | | Comments:; - Data on ART were available for 80% of the multiple births born to 75% of the mothers.; - There is potential selection bias as the missing data points could differ significantly.; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: + Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | | BPD | No BPD | Total
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | ART | 33 | 148 | 181
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | Natural | 37 | 164 | 201
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | Total | 70 | 312 | 382
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | | Value | Lower 95% CI | Upper 95% CI
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | Odds rat | 0.99 | 0.59 | 1.66
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | 2) Risk of death:
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | | Death | No death | Total
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | ART | 28 | 153 | 181
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | Natural | 38 | 163 | 201
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | Total | 66 | 316 | 382
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | | Value | Lower 95% CI | Upper 95% CI
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | Odds rat | 0.79 | 0.46 | 1.34
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | 3) Risk of death or BPD:
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | | Death or BPD | No death or BPD | Total
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | ART | 61 | 120 | 181
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | Natural | 75 | 126 | 201
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | Total | 136 | 246 | 382
Hashimoto, Lindsell, Brewer, et al., 2004 #13870 | Geographical location: Cincinnati, Ohio Study dates: Jan 1996 – Dec 2000 Size of population: 382 infants (201 natural conception, 181 ART) Study type: Case-control | | | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 0.85 | 0.56 | 1.30
Hernandez-Diaz, Werler, and Mitchell, 2007 #71320 | Geographical location: U.S. and Canada (general population) Study dates: 1998-206 Size of population (no. of patients): 5151 Study type: Cohort | Age: < 25: 1162 25–30: 1400 31–35: 1761 > 35: 814 Race/ethnicity (n [%]): White: 3777 Black: 348 Other: 1025 Diagnoses (n [%]): NR Inclusion criteria: Mothers of malformed infants born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Self-report of physician diagnosis of high blood pressure, preeclampsia, or toxemia | 1) Gestational hypertension: | | | | Comments: Exposure and outcome ascertainment based on subject self-report Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: - Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Hernandez-Diaz, Werler, and Mitchell, 2007 #71320 | Geographical location: U.S. and Canada (general population) Study dates: 1998-206 Size of population (no. of patients): 5151 Study type: Cohort | | Definition(s) of outcome(s): Self-report of physician diagnosis of high blood pressure, preeclampsia, or toxemia | | Gest HTN + | Gest HTN - | Total
Hernandez-Diaz, Werler, and Mitchell, 2007 #71320 | Geographical location: U.S. and Canada (general population) Study dates: 1998-206 Size of population (no. of patients): 5151 Study type: Cohort | | Definition(s) of outcome(s): Self-report of physician diagnosis of high blood pressure, preeclampsia, or toxemia | Infertility treatment | 55 | 294 | 349
Hernandez-Diaz, Werler, and Mitchell, 2007 #71320 | Geographical location: U.S. and Canada (general population) Study dates: 1998-206 Size of population (no. of patients): 5151 Study type: Cohort | | Definition(s) of outcome(s): Self-report of physician diagnosis of high blood pressure, preeclampsia, or toxemia | No infert treatment | 423 | 4339 | 4762
Hernandez-Diaz, Werler, and Mitchell, 2007 #71320 | Geographical location: U.S. and Canada (general population) Study dates: 1998-206 Size of population (no. of patients): 5151 Study type: Cohort | | Definition(s) of outcome(s): Self-report of physician diagnosis of high blood pressure, preeclampsia, or toxemia | Total | 478 | 4633 | 5111
Hernandez-Diaz, Werler, and Mitchell, 2007 #71320 | Geographical location: U.S. and Canada (general population) Study dates: 1998-206 Size of population (no. of patients): 5151 Study type: Cohort | | Definition(s) of outcome(s): Self-report of physician diagnosis of high blood pressure, preeclampsia, or toxemia | | Value | Lower 95% CI | Upper 95% CI
Hernandez-Diaz, Werler, and Mitchell, 2007 #71320 | Geographical location: U.S. and Canada (general population) Study dates: 1998-206 Size of population (no. of patients): 5151 Study type: Cohort | | Definition(s) of outcome(s): Self-report of physician diagnosis of high blood pressure, preeclampsia, or toxemia | Rel risk | 1.77 | 1.37 | 2.30
2) OR after adjustment for parity, prepregnancy BMI, number of fetuses 1.3 (1.0–1.9)
Hjelmstedt, Widstrom, Wramsby, et al., 2003 #17130 | Geographical location: Stockholm, Sweden Study dates: Recruited May 1997–Jan 2000 Size of population: 57 women, 55 men who conceived after IVF; 43 women, 39 men who conceived naturally Study type: Case-control Compared women and men who conceived by IVF to those who conceived naturally regarding psychological variables | Age: Mean (SD): IVF women: 32.3 (2.1) Control women: 31.2 (1.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 26.3% Male factor: 26.3% Other: “Female” 36.8%, “combination of female and male” 10.5% Inclusion criteria:; - Women 29–36 yo; - Primiparous; - In good health; - Pregnant with singleton; - Nonsmokers; - Adequate Swedish language skills; - Men with adequate Swedish language skills; Exclusion criteria: NR | Definition(s) of outcome(s): Infertility Reaction Scale (IRS) used to assess recalled distress related to infertility Barnett scale to assess satisfaction with relationship with partner Karolinska Scales of Personality (KSP) used to measure personality traits Spielberger State and Trait Anxiety Inventory (STAI) Emotional Responses to Pregnancy Scale (ERPS) | Women in IVF group reported more muscular tension, irritability Men in IVF group reported more somatic anxiety, detachment, indirect aggression, guilt, psychic anxiety No difference between 2 groups for STAI | | | | Comments:; - 25% of eligible patients not approached because of busy recruiters' schedules; - 25% of couples declined to participate; - Authors state no significant difference between participants & nonparticipants with respect to cause of infertility, age, duration of infertility, # previous IVF treatments; - Controls had cohabitated for fewer yrs than IVF; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: - Appropriateness of the control population: + Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: - Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | Geographical location: Tel Aviv, Israel Study dates: Jan 1995 - Dec 1997 Size of population: 322 ICSI, 201 IVF Study type: Cohort (retrospective) Retrospective comparison of outcomes of IVF vs ICSI pregnancies. Questionnaires mailed 1–3yr after delivery | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | No sig diff in mean birth wts by plurality in IVF vs ICSI. Only 2 major malformations, both in ICSI grp 1) Neonatal complications - singletons: | | | | Comments:; - No mention made of response rate; - No objective assessment of outcomes by record review or exams (relied on parental reports); Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: - Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | | neo comp+ | neo comp- | Total
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | ICSI | 51 | 71 | 122
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | IVF | 58 | 140 | 198
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | Total | 109 | 211 | 320
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | | Value | Lower 95% CI | Upper 95% CI
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | Odds rat | 1.73 | 1.08 | 2.78
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | Twins
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | | neo comp+ | neo comp- | Total
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | ICSI | 41 | 123 | 164
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | IVF | 22 | 75 | 97
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | Total | 63 | 198 | 261
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | | Value | Lower 95% CI | Upper 95% CI
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | Odds rat | 1.14 | 0.63 | 2.05
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | Triplets
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | | neo comp+ | neo comp- | Total
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | ICSI | 12 | 14 | 26
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | IVF | 8 | 9 | 17
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | Total | 20 | 23 | 43
Hourvitz, Pri-Paz, Dor, et al., 2005 #39160 | | Age: Mean (SD): IVF 31.8 (5.0), ICSI 30.6 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Embryo transfers for IVF or ICSI during study period. Exclusion criteria: NR | Definition(s) of outcome(s): Major malf = condition requiring surgical correction or causing functional impairment | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 0.96 | 0.28 | 3.28
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | Age: SC: 31.8 (3.7) IUI: 32.1 (3.0) IVF/ICSI: 33.7 (4.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria:; - Hypertension; - Diabetes; - < 24 wk gestation; - Higher-order multiples; - Incomplete data | Definition(s) of outcome(s): Preterm birth Low birthweight | 1) Preterm birth, IUV vs. spontaneous conception: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | | PTB + | PTB - | Total
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | IUI | 23 | 40 | 63
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | Spontaneous | 20 | 30 | 50
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | Total | 43 | 70 | 113
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | | Value | Lower 95% CI | Upper 95% CI
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | Rel risk | 0.91 | 0.57 | 1.46
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | 2) Low birthweight, IUI vs. spontaneous conception:
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | | LBWT + | LBWT - | Total
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | IUI | 29 | 34 | 63
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | Spontaneous | 18.5 | 31.5 | 50
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | Total | 47.5 | 65.5 | 113
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | | Value | Lower 95% CI | Upper 95% CI
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | Rel risk | 1.24 | 0.79 | 1.95
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | 3) Preterm birth, IVF/ICSI vs. spontaneous:
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | | PTB + | PTB - | Total
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | IVF/ICSI | 35 | 46 | 81
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | Spontaneous | 20 | 30 | 50
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | Total | 55 | 76 | 131
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | | Value | Lower 95% CI | Upper 95% CI
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | Rel risk | 1.08 | 0.71 | 1.65
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | 4) Low birthweight, IVF/ICSI vs. spontaneous:
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | | LBWT + | LBWT - | Total
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | IVF/ICSI | 39 | 42 | 81
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | Spontaneous | 19 | 31 | 50
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | Total | 58 | 73 | 131
Huang, Au, Chien, et al., 2006 #52630 | Geographical location: Taipei, Taiwan Study dates: 1992-2001 Size of population (no. of patients): 194 twin sets Spontaneous conception (SC) n = 50 IUI n = 63 IVF/ICSI n = 81 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth Low birthweight | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.27 | 0.83 | 1.93
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | Age: Mean (SD): Controls: 36 (4) Fresh IVF: 36 (3) Fresh ICSI: 34 (4) Frozen IVF: 35 (4) Frozen ICSI: 33 (3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF or ICSI with fresh (n = 149) or frozen embryos (n = 85), “known to have normal karyotype or babies did not show signs of chromosomal abnormalities at birth”; - Controls:; Exclusion criteria:; - > 1 gestational sac on ultrasound at 5–6 weeks | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | 1) Median PAPP-A multiples of median: | | | | Comments:; - No adjustment for multiple comparisons; - Proportion of women who would have been referred for testing not reported; - Relevant obstetric outcomes (IUGR, etc.) not reported; - Rates of chromosomal abnormalities in ART pregnancies not reported; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: - Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | Group | N | Median
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | Controls | 401 | 1.00
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | Fresh
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | IVF | 95 | 0.83
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | ICSI | 57 | 0.70
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | Frozen
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | IVF | 54 | 0.95
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | ICSI | 31 | 0.66
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | 2) Median free β-hCG multiples of median:
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | Group | N | Median
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | Controls | 401 | 1.00
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | Fresh
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | IVF | 95 | 0.87
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | ICSI | 57 | 0.82
Hui, Lam, Tang, et al., 2005 #41860 | Geographical location: Hong Kong, China Study dates: 1998-2002 Size of population (no. of patients): 234 ART 401 spontaneous conceptions Study type: Cohort | | Definition(s) of outcome(s): PAPP-A Free β-hCG Multiples of the median at 10–14 weeks, adjusted for maternal weight | Frozen
IVF | 54 | 1.21
ICSI | 31 | 0.96
Hui, Tang, Lam, et al., 2005 #9670 | Geographical location: Hong Kong, China Study dates: Jan 1997–Dec 2002 Size of population (no. of patients): 16,673 spontaneous pregnancies 119 Fresh IVF 62 Frozen IVF 81 Fresh ICSI 39 Frozen ICS Study type: Cohort | Age: Mean age (± SD) for controls (31.7 ± 3.7) significantly lower than for all ART groups (33.6–35.8) Race/ethnicity (n [%]):; - Asian: 96.5% spontaneous, 98% ART; - No Caucasians in ART group, 127 (0.8%) in spontaneous group; Diagnoses (n [%]): NR Inclusion criteria:; - Singleton pregnancy; - Known “normal outcomes”; Exclusion criteria: Unknown or abnormal fetal outcome, including chromosomal abnormalities | Definition(s) of outcome(s): Nuchal translucency measured by ultrasound at 10–14 weeks Mean gestational age in days calculated on basis of ultrasound measurement (86.1 ± 7.1) significantly lower in spontaneous compared to ART pregnancy by approximately 2 days | 1) False positives based on 1:186 risk from general population: | | | | Comments:; - Unclear if dating for ART pregnancies based on day of transfer or ultrasound measurement; - No adjustment for multiple comparisons; - Other relevant obstetric outcomes (IUGR, etc) not reported; Rates of chromosomal abnormalities in ART pregnancies not reported Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: - Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Hui, Tang, Lam, et al., 2005 #9670
Hui, Tang, Lam, et al., 2005 #9670 | | | | Group | N in group | N false + | %
Hui, Tang, Lam, et al., 2005 #9670 | | | | Controls | 16673 | 834 | 5%
Hui, Tang, Lam, et al., 2005 #9670 | | | | Fresh
Hui, Tang, Lam, et al., 2005 #9670 | | | | IVF | 119 | 12 | 10.1%
Hui, Tang, Lam, et al., 2005 #9670 | | | | ICSI | 62 | 9 | 14.5%
Hui, Tang, Lam, et al., 2005 #9670 | | | | Frozen
Hui, Tang, Lam, et al., 2005 #9670 | | | | IVF | 81 | 7 | 8.6%
Hui, Tang, Lam, et al., 2005 #9670 | | | | ICSI | 39 | 3 | 10.3%
Hui, Tang, Lam, et al., 2005 #9670 | | | | 2) Relative risk of false positive:
Hui, Tang, Lam, et al., 2005 #9670 | | | | | False + | - | Total
Hui, Tang, Lam, et al., 2005 #9670 | | | | ART + | 31 | 270 | 301
Hui, Tang, Lam, et al., 2005 #9670 | | | | Spont | 864 | 15909 | 16773
Hui, Tang, Lam, et al., 2005 #9670 | | | | Total | 895 | 16179 | 17074
| Value | Lower 95% CI | Upper 95% CI
Rel risk | 2 | 1.42 | 2.81
Hui, Tang, Ng, et al., 2006 #52670 | Geographical location: Hong Kong, China Study dates: 2001-2003 Size of population (no. of patients): 3317 spontaneous singletons 19 spontaneous dichorionic twins 27 ART dichorionic twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): Singletons: 95.5% Asian Twins: 93.5% Asian Diagnoses (n [%]): NR Inclusion criteria:; - Dichorionic twins; - Known normal outcomes; Exclusion criteria: Trisomy, fetal demise | Definition(s) of outcome(s): Nuchal translucency at 10–14 weeks, multiples of median, adjusted for gestational age | 1) Nuchal translucency, multiples of median (calculated as if each twin independent observation): Singleton: 1.00 (range, 0.12–3.24) Spontaneous twin: 1.07 (range, 0.64–1.94) ART twin: 1.02 (range, 0.61–1.87) | | | | Comments:; - No adjustment for multiple comparisons; - Each twin assumed to be independent—no control for; - Small sample size; - False positive rates not reported; - Other obstetric outcomes not reported; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | Geographical location: Aarhus, Denmark Study dates: Jan 1995 – Dec 2000 Size of population: IVF/ICSI 9,444, non-IVF 395,025 Study type: All liveborns in study period, analyzed retrospectively for cerebral palsy by mode of conception and number of embryos transferred - idea was to assess risk of CP in IVF/ICSI children, and in IVF/ICSI pregnancies affected by vanishing twin | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | 1) CP by mode of conception: | | | | Comments:; - May have underestimated CP rate bc of wide range of f/u (some children may have been Dx'd after 1yo); - Disproportionate # of IVF children had shorter f/u time (bc number of IVF treatments increased over study period), so may have underestimated CP disproportionately in this grp; - Could not assess for vanishing twins in non-IVF/ICSI pregnancies; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: - Appropriateness of the control population: + Verification that the control is free of cancer: - Comparability of cases and controls with respect to potential confounders: ?not stated Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | | CP+ | CP- | Total
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | IVF/ICSI | 41 | 9403 | 9444
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | not | 1016 | 394009 | 395025
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | Total | 1057 | 403412 | 404469
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | | Value | Lower 95% CI | Upper 95% CI
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | Odds rat | 1.69 | 1.24 | 2.31
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | Results of IVF/ICSI pregnancies by plurality and by presence or absence of vanishing twin (#embryos transferred >1 for singletons, >2 for twins):
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | 2) Singletons < 32w:
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | | CP+ | CP- | Total
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | van | 4 | 79 | 83
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | no van | 0.5 | 5 | 5.5
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | Total | 4.5 | 84 | 88.5
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | | Value | Lower 95% CI | Upper 95% CI
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | Odds rat | 0.51 | 0.02 | 10.97
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | 3) Twins < 32w:
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | | CP+ | CP- | Total
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | van | 4 | 56 | 60
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | no van | 4 | 230 | 234
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | Total | 8 | 286 | 294
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | | Value | Lower 95% CI | Upper 95% CI
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | Odds rat | 4.11 | 1.00 | 16.93
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | 4) Singletons ≥ 32w:
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | | CP+ | CP- | Total
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | van | 16 | 5090 | 5106
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | no van | 0.5 | 487 | 487.5
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | Total | 16.5 | 5577 | 5593.5
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | | Value | Lower 95% CI | Upper 95% CI
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | Odds rat | 3.06 | 0.18 | 51.18
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | 5) Twins ≥ 32w:
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | | CP+ | CP- | Total
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | van | 4 | 775 | 779
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | no van | 8 | 2487 | 2495
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | Total | 12 | 3262 | 3274
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | | Value | Lower 95% CI | Upper 95% CI
Hvidtjorn, Grove, Schendel, et al., 2005 #41270 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn children born in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): CP children identified through National Register of Hospital Discharges (mandatory reporting, recorded prospectively). F/u period 1–7yr | Odds rat | 1.60 | 0.48 | 5.34
Cox regression analysis including plurality at delivery, GA, amt age, sex, parity, education - showed increased risk of CP in pregnancies where # of gestations at delivery < # gestations originally transferred (HRR 2.30 [0.99,5.32])
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | Geographical location: Denmark Study dates: Children born between January 1995–December 2000 Size of population (no. of patients): 403,968 singleton/twins (307,960 mothers). 9255 (2.3%) from IVF (7000 mothers) Study type: Cohort | Age: 23% of IVF mothers <30, compared to 70% of non-IVF mothers Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All liveborn singleton and twins in Denmark during study period Exclusion criteria: NR | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | 1) SGA—IVF singletons: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: - (discharge summary/registry data) Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results:+
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | | Out + | Out - | Total
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | IVF + | 250 | 5435 | 5685
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | IVF - | 12266 | 371653 | 383919
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | Total | 12516 | 377088 | 389604
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | | Value | Lower 95% CI | Upper 95% CI
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | Rel risk | 1.38 | 1.22 | 1.56
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | 2) SGA—IVF twins:
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | | Out + | Out - | Total
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | IVF + | 548 | 3022 | 3570
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | IVF - | 1623 | 9141 | 10764
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | Total | 2171 | 12163 | 14334
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | | Value | Lower 95% CI | Upper 95% CI
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | Rel risk | 1.02 | 0.93 | 1.11
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | 3) CP: IVF singletons:
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | | Out + | Out - | Total
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | IVF + | 20 | 5665 | 5685
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | IVF - | 947 | 382972 | 383919
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | Total | 967 | 388637 | 389604
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | | Value | Lower 95% CI | Upper 95% CI
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | Rel risk | 1.43 | 0.92 | 2.22
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | 4) CP:IVF twins:
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | | Out + | Out - | Total
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | Exp + | 20 | 3550 | 3570
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | Exp - | 61 | 10733 | 10794
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | Total | 81 | 14283 | 14364
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | | Value | Lower 95% CI | Upper 95% CI
Hvidtjorn, Grove, Schendel, et al., 2006 #52710 | | | Definition(s) of outcome(s): Cerebral palsy diagnosis in medical records—diagnostic tests not described | Rel risk | 0.99 | 0.60 | 1.64
5) Risk associated with IVF decreased, CI's cross 1 after controlling for SGA, prematurity. Number of cases too small to draw conclusions about specific treatments or diagnoses
Isaksson, Gissler, and Tiitinen, 2002 #1670 | Geographical location: Helsinki, Finland Study dates: Jan 1993–Mar 1999 Size of population: Study patients: 107 women with unexplained infertility, with 118 pregnancies Spontaneous controls (Ctrl I): 445 women/545 children of spontaneous pregnancies; ART controls (Ctrl II): 2377 women/2853 children of all other ART pregnancies Study type: Case-control | Age: Age data reported only categorically Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Pregnancies after IVF or ICSI to women with unexplained infertility at one hospital during study period; - Ctrl groups chosen from Finnish Medical Birth Registry:; I = women with non-assisted pregnancy, matched by age, parity, yr of delivery, mother's residence, plurality II = all women delivering singletons or twins after IVF, ICSI, or FET in southern Finland during study period Exclusion criteria: One set of triplets | Definition(s) of outcome(s): Delivery = live or stillbirth > 22 wk or BW > 500 g SGA = BW < -2SD of Finnish population mean for sex Major anomaly = significant congenital structural anomaly, chromosomal defect, or congenital hypothyroidism PIH = BP ≥ 140/90 after 20 wk, or increase in SBP ≥ 30 or DBP ≥ 15 Unexplained infertility = comprehensive infertility evaluation failed to reveal any apparent cause | Note raw data not given, just %s 1) C/S in singletons, study group vs. spontaneously conceived ctrls: | | | | Comments:; - Unclear whether ctrl grp II contains pregnancies conceived by ART with unexplained infertility (study grp); - Those in study grp were more likely married or cohabiting, nonsmokers than spont grp; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + for grp I, for grp II, unclear how they differed from study subjects Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: - (see above) Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | | C/S + | C/S - | Total
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Study | 17 | 52 | 69
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Ctrl I | 70 | 275 | 345
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Total | 87 | 327 | 414
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | | Value | Lower 95% CI | Upper 95% CI
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Odds rat | 1.28 | 0.70 | 2.36
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | 2) LBW in singletons, study grp vs. spont ctrls:
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | | LBW + | LBW - | Total
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Study | 2 | 67 | 69
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Ctrl I | 20 | 325 | 345
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Total | 22 | 392 | 414
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | | Value | Lower 95% CI | Upper 95% CI
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Odds rat | 0.49 | 0.11 | 2.12
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Similarly, no difference in twins 3) LBW in sing, study grp vs. all ART:
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | | LBW + | LBW - | Total
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Study | 2 | 67 | 69
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Ctrl II | 95 | 1806 | 1901
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Total | 97 | 1873 | 1970
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | | Value | Lower 95% CI | Upper 95% CI
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Odds rat | 0.57 | 0.14 | 2.35
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Similarly, no difference in twins 4) Major congenital anomalies in singletons, study grp vs. spont ctrls:
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | | Anom + | Anom - | Total
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Study | 5 | 64 | 69
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Ctrl I | 12 | 333 | 345
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Total | 17 | 397 | 414
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | | Value | Lower 95% CI | Upper 95% CI
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Odds rat | 2.17 | 0.74 | 6.37
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Similarly, no difference in twins 5) Major congenital anomalies in singletons, study grp vs. all ART:
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | | Anom+ | Anom- | Total
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Study | 5 | 64 | 69
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Ctrl II | 84 | 1817 | 1901
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Total | 89 | 1881 | 1970
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | | Value | Lower 95% CI | Upper 95% CI
Isaksson, Gissler, and Tiitinen, 2002 #1670 | | | | Odds rat | 1.69 | 0.66 | 4.31
Similarly, no difference in twins
Jensen, Sharif, Svare El, et al., 2007 #71490 | Geographical location: Denmark Study dates: 1965-1998 Size of population (no. of patients): 54,362 Study type: Cohort | Age: Median: 30 for first evaluation, 40 for follow-up Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Referred to Danish hospital or clinic for evaluation of infertility Exclusion criteria: NR | Definition(s) of outcome(s): Breast cancer in Danish cancer registry | 1) Adjusted risks for use of infertility drugs (compared to diagnosis of infertility and no treatment, adjusted for age at follow-up, calendar year, gravidity, and paritiy) Gonadotropins 1.20 (0.82–1.78) Clompihene 1.08 (0.85–1.39) hCG 0.94 (0.73–1.21) GnRH 1.28 (0.75–2.19) Progesterone 3.36 (1.60–7.07) | | | | Comments:; - Not adjusted for multple drug usage; - Progesterone used as part of IVF regimen; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes:+ Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Jun and Milki, 2004 #13000 | Geographical location: Stanford, CA Study dates: 1998 – 2003 Size of population: N = 623 (258 cases of IVF + assisted hatching, 365 controls IVF w/o assisted hatching) Study type: Cohort | Age: Mean (SD): 37.6 (4.1) for cases 37.8 (5.3) controls Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - All clinical pregnancies conceived after day 3 transfers; Exclusion criteria: NR | Definition(s) of outcome(s): Clinical pregnancy = gestational sac on ultrasound or ectopic pregnancy diagnosed by ultrasound, laparoscopy, or absence of gestational sac and increasing hcg after negative D&C | 1) Ectopic pregnancy associated with assisted hatching (AH): | | | | Comments: There was no difference in the incidence of tubal disease between cases vs. controls; however, there are no data describing why assisted hatching was chosen among cases and not among controls, which could cause some bias in this retrospective study. Quality assessment: Valid ascertainment of cases: Unbiased selection of cases: Appropriateness of the control population: Verification that the control is free of cancer: Comparability of cases and controls with respect to potential confounders: Validated dietary assessment method: Appropriateness of statistical analyses:
Jun and Milki, 2004 #13000 | Geographical location: Stanford, CA Study dates: 1998 – 2003 Size of population: N = 623 (258 cases of IVF + assisted hatching, 365 controls IVF w/o assisted hatching) Study type: Cohort | | | | Ect + | Ect -
Jun and Milki, 2004 #13000 | Geographical location: Stanford, CA Study dates: 1998 – 2003 Size of population: N = 623 (258 cases of IVF + assisted hatching, 365 controls IVF w/o assisted hatching) Study type: Cohort | | | Assisted hatching | 14 | 244 | 258
Jun and Milki, 2004 #13000 | Geographical location: Stanford, CA Study dates: 1998 – 2003 Size of population: N = 623 (258 cases of IVF + assisted hatching, 365 controls IVF w/o assisted hatching) Study type: Cohort | | | Control | 8 | 357 | 365
Jun and Milki, 2004 #13000 | Geographical location: Stanford, CA Study dates: 1998 – 2003 Size of population: N = 623 (258 cases of IVF + assisted hatching, 365 controls IVF w/o assisted hatching) Study type: Cohort | | | | 22 | 601 | 623
Jun and Milki, 2004 #13000 | Geographical location: Stanford, CA Study dates: 1998 – 2003 Size of population: N = 623 (258 cases of IVF + assisted hatching, 365 controls IVF w/o assisted hatching) Study type: Cohort | | | | | Lower 95% CI | Upper 95 % CI
Rel risk | 2.48 | 1.05 | 5.82
Jun and Milki, 2007 #71540 | Geographical location: Palo Alto, CA Study dates: Jan 1998–Dec 2005 Size of population (no. of patients): 744 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Fresh or frozen thawed blastocyst (day 5) transfer Exclusion criteria: NR | Definition(s) of outcome(s): Ectopic pregnancy | 1) Ectopic pregnancy: | | | | Comments: Tubal disease more common in frozen group (32.4% vs. 18.3%) Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes:+ Adequate follow-up period:+ Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Jun and Milki, 2007 #71540 | Geographical location: Palo Alto, CA Study dates: Jan 1998–Dec 2005 Size of population (no. of patients): 744 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Fresh or frozen thawed blastocyst (day 5) transfer Exclusion criteria: NR | Definition(s) of outcome(s): Ectopic pregnancy | | Out + | Out - | Total
Jun and Milki, 2007 #71540 | Geographical location: Palo Alto, CA Study dates: Jan 1998–Dec 2005 Size of population (no. of patients): 744 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Fresh or frozen thawed blastocyst (day 5) transfer Exclusion criteria: NR | Definition(s) of outcome(s): Ectopic pregnancy | Frozen | 5 | 175 | 180
Jun and Milki, 2007 #71540 | Geographical location: Palo Alto, CA Study dates: Jan 1998–Dec 2005 Size of population (no. of patients): 744 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Fresh or frozen thawed blastocyst (day 5) transfer Exclusion criteria: NR | Definition(s) of outcome(s): Ectopic pregnancy | Fresh | 10 | 554 | 564
Jun and Milki, 2007 #71540 | Geographical location: Palo Alto, CA Study dates: Jan 1998–Dec 2005 Size of population (no. of patients): 744 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Fresh or frozen thawed blastocyst (day 5) transfer Exclusion criteria: NR | Definition(s) of outcome(s): Ectopic pregnancy | Total | 15 | 729 | 744
Jun and Milki, 2007 #71540 | Geographical location: Palo Alto, CA Study dates: Jan 1998–Dec 2005 Size of population (no. of patients): 744 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Fresh or frozen thawed blastocyst (day 5) transfer Exclusion criteria: NR | Definition(s) of outcome(s): Ectopic pregnancy | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.57 | 0.54 | 4.52
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | Geographical location: Stockholm, Sweden Study dates: 1982 – April 2001 Size of population: 16,280 IVF children Study type: Cohort (retrospective) Infants conceived by IVF compared to all infants born in study period registered with Swedish medical Birth Register | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All infants born in study period registered with Swedish medical Birth Register Exclusion criteria: Embryo transfers after April 1, 2001 | Definition(s) of outcome(s): Congenital malformation info obtained from diagnostic codes in Swedish Medical Birth Register, Swedish Registry of Congenital Malformations, and Swedish Hospital Discharge Register For IVF vs all births analysis, only SMBR data used (except for some specific anomalies). Then “weeded out” common conditions, “which are variable in registration, and sometimes associated with preterm birth & LBW” (preauricular appendix, PDA, SUA, undescended test, hip subluxation, minor skin malf) | 1) Congenital malformations, IVF vs all births in SMBR: | | | | Comments: I believe #1 comparisons included IVF children in both grps Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: (see above) Verification that the control is free of cancer: - (see above) Comparability of cases and controls with respect to potential confounders: Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | | Malf+ | Malf- | Total
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | IVF | 811 | 15469 | 16280
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | all | 80881 | 1959062 | 2039943
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | Total | 81692 | 1974531 | 2056223
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | | Value | Lower 95% CI | Upper 95% CI
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | Odds rat | 1.27 | 1.18 | 1.36
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | “weeded”:
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | | Malf+ | Malf- | Total
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | IVF | 535 | 15745 | 16280
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | all | 45892 | 1994051 | 2039943
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | Total | 46427 | 2009796 | 2056223
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | | Value | Lower 95% CI | Upper 95% CI
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | Odds rat | 1.48 | 1.35 | 1.61
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | Significantly elevated OR for many specific anomalies, IVF vs all (obs vs expected based on actual numbers from all 3 sources), adjusted for yr of birth, and excluding those with chromosomal anomalies (see Table 4, too many to put in table) Adjustment made for yr of birth, maternal age, parity, yrs of involuntary childlessness (20% missing data), maternal smoking. Found OR's decreased after adjustment (became NS when all adjustments applied) 2) Malformations, IVF grp only by IVF method:
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | | Malf+ | Malf- | Total
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | ICSI | 428 | 4521 | 4949
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | IVF | 913 | 10370 | 11283
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | Total | 1341 | 14891 | 16232
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | | Value | Lower 95% CI | Upper 95% CI
Kallen, Finnstrom, Nygren, et al., 2005 #42180 | | | | Odds rat | 1.08 | 0.95 | 1.21
Also looked at fresh vs frozen sperm, ejaculated vs epidiymal vs testicular sperm, no signif diff in any comparison.
Kallen and Robert-Gnansia, 2005 #38960 | Geographical location: Lund, Sweden Study dates: July 1995 – 2002 Size of population: 398 cases, 728,822 controls Study type: Case-control Cases of craniosynostosis identified, then compared to all women who gave birth during study period | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Cases: infants with craniosynostosis born 1995 - 2002 identified through Medical Birth Registry, Registry of Congenital Malformations, and Hospital Discharge Registry. Exclusion criteria: Infants with known chromosomal anomalies | Definition(s) of outcome(s): Expected number of exposures calculated from population data | 1) treatment for infertility as risk factor: | | | | Comment:; - Not known what type of craniosynostosis cases had; some may have been due to genetic causes, not drug exposures.; - Drug usage based on prescription data; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: Comparability of cases and controls with respect to potential confounders: + (age and smoking only) Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Kallen and Robert-Gnansia, 2005 #38960 | | | Definition(s) of outcome(s): Expected number of exposures calculated from population data | | cran+ | cran- | Total
Kallen and Robert-Gnansia, 2005 #38960 | | | Definition(s) of outcome(s): Expected number of exposures calculated from population data | infert+ | 14 | 22756 | 22770
Kallen and Robert-Gnansia, 2005 #38960 | | | Definition(s) of outcome(s): Expected number of exposures calculated from population data | infert- | 384 | 706066 | 706450
Kallen and Robert-Gnansia, 2005 #38960 | | | Definition(s) of outcome(s): Expected number of exposures calculated from population data | Total | 398 | 728822 | 729220
Kallen and Robert-Gnansia, 2005 #38960 | | | Definition(s) of outcome(s): Expected number of exposures calculated from population data | | Value | Lower 95% CI | Upper 95% CI
Kallen and Robert-Gnansia, 2005 #38960 | | | Definition(s) of outcome(s): Expected number of exposures calculated from population data | Odds rat | 1.13 | 0.66 | 1.93
Specific drugs analyzed by observed: expected numbers of exposed women with infants with craniosynostosis; significant RR for first-trimester exposure to anticonvulsants (RR 6.9 [2.3–16.2])
Kanyo and Konc, 2003 #15580 | Geographical location: Budapest, Hungary Study dates: Dec 1998 – Dec 1999 Size of population: 134 children born after laser-assisted hatching (LAH) 894 children born during same period after spontaneous conception (used as control grp) Study type: Cohort Assessed prenatal karyotype if available, perinatal data, major/minor malformations, neonatal problems. Record review + phone interviews after delivery, at 12 wks, 6 mos, and 1 yr. Divided into Grp I (>35yo), II (>3 IVF cycles), III (both >35yo and >3 IVF cycles) | Age: Mean (range): Grp I: 37.0 (35–44) Grp II: 32.1 (25–35) Grp III: 38.5 (36–44) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Consecutive first 96 deliveries after laser-assisted hatching (LAH) Exclusion criteria: NR | Definition(s) of outcome(s): Major malformation = causing functional impairment or requiring surgical correction. | No data on C/S rates, fetal reduction Authors report major malformation rate of 3% at their hospital. 1) Laser-assisted hatching as risk factor for major malformation: | | | | Comments:; - No power analysis; small sample size makes conclusions regarding safety invalid.; - No data presented re: completeness of f/u; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): not prospective, but included all cases of LAH Large sample size: - Adequate description of the cohort: - Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: no data presented Analysis (multivariate adjustments) and reporting of results: -
Kanyo and Konc, 2003 #15580 | | | Definition(s) of outcome(s): Major malformation = causing functional impairment or requiring surgical correction. | | Maj malform + | Maj malform - | Total
Kanyo and Konc, 2003 #15580 | | | Definition(s) of outcome(s): Major malformation = causing functional impairment or requiring surgical correction. | LAH + | 2 | 132 | 134
Kanyo and Konc, 2003 #15580 | | | Definition(s) of outcome(s): Major malformation = causing functional impairment or requiring surgical correction. | Risk - | 27 | 867 | 894
Kanyo and Konc, 2003 #15580 | | | Definition(s) of outcome(s): Major malformation = causing functional impairment or requiring surgical correction. | Total | 29 | 999 | 1028
Kanyo and Konc, 2003 #15580 | | | Definition(s) of outcome(s): Major malformation = causing functional impairment or requiring surgical correction. | | Value | Lower 95% CI | Upper 95% CI
Kanyo and Konc, 2003 #15580 | | | Definition(s) of outcome(s): Major malformation = causing functional impairment or requiring surgical correction. | Rel risk | 0.49 | 0.12 | 2.05
Kanyo and Konc, 2003 #15580 | | | Definition(s) of outcome(s): Major malformation = causing functional impairment or requiring surgical correction. | 2) Laser-assisted hatching as risk factor for minor malformation:
Kanyo and Konc, 2003 #15580 | | | Definition(s) of outcome(s): Major malformation = causing functional impairment or requiring surgical correction. | | Min malform + | Min malform - | Total
Kanyo and Konc, 2003 #15580 | | | Definition(s) of outcome(s): Major malformation = causing functional impairment or requiring surgical correction. | LAH + | 14 | 120 | 134
Kanyo and Konc, 2003 #15580 | | | Definition(s) of outcome(s): Major malformation = causing functional impairment or requiring surgical correction. | Risk - | 99 | 795 | 894
Kanyo and Konc, 2003 #15580 | | | Definition(s) of outcome(s): Major malformation = causing functional impairment or requiring surgical correction. | Total | 113 | 915 | 1028
Kanyo and Konc, 2003 #15580 | | | Definition(s) of outcome(s): Major malformation = causing functional impairment or requiring surgical correction. | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.94 | 0.56 | 1.60
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | Age: Mean (SD): ICSI: 32.9 (3.9) Controls: 27.0 (4.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Cases recruited after the 16^th^ wk and followed through the pregnancy, 1998 - 2000; - Control newborns from 1993-2001 according to the same protocol for the study cohort; - No other criteria described; Exclusion criteria: NR | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | 1) Major malformations: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for genomic test: NA Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: n/a Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Malform+ | Malform - | Total
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | ICSI | 298 | 3074 | 3372
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Natural | 488 | 7528 | 8016
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Total | 786 | 10602 | 11388
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Value | Lower 95% CI | Upper 95% CI
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Rel risk | 1.45 | 1.26 | 1.67
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | 2) Preterm birth:
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | PTB + | PTB - | Total
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | ICSI | 363 | 2324 | 2687
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Natural | 568 | 7370 | 7938
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Total | 931 | 9694 | 10625
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Value | Lower 95% CI | Upper 95% CI
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Rel risk | 1.89 | 1.67 | 2.14
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | 3) Preeclampsia:
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Pre-X + | Pre-X - | Total
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | ICSI | 269 | 2418 | 2687
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Natural | 578 | 7360 | 7938
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Total | 847 | 9778 | 10625
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Value | Lower 95% CI | Upper 95% CI
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Rel risk | 1.37 | 1.20 | 1.58
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | 4) Placental abruption:
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Abrupt + | Abrupt - | Total
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | ICSI | 62 | 2625 | 2687
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Natural | 89 | 7849 | 7938
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Total | 151 | 10474 | 10625
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Value | Lower 95% CI | Upper 95% CI
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Rel risk | 2.06 | 1.49 | 2.84
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | 5) Placenta previa:
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Previa + | Previa - | Total
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | ICSI | 53 | 2634 | 2687
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Natural | 28 | 7910 | 7938
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Total | 81 | 10544 | 10625
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Value | Lower 95% CI | Upper 95% CI
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Rel risk | 5.59 | 3.54 | 8.82
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | 6) Placental insufficiency:
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Insuff + | Insuff - | Total
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | ICSI | 103 | 2584 | 2687
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Natural | 83 | 7855 | 7938
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Total | 186 | 10439 | 10625
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Value | Lower 95% CI | Upper 95% CI
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Rel risk | 3.67 | 2.75 | 4.88
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | 7) Oligohydramnios:
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Oligo + | Oligo- | Total
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | ICSI | 65 | 2622 | 2687
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Natural | 87 | 7851 | 7938
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Total | 152 | 10473 | 10625
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Value | Lower 95% CI | Upper 95% CI
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Rel risk | 2.21 | 1.61 | 3.03
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | 8) Cervical incompetence:
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Incomp + | Incomp - | Total
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | ICSI | 270 | 2417 | 2687
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Natural | 496 | 7442 | 7938
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Total | 766 | 9859 | 10625
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Value | Lower 95% CI | Upper 95% CI
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Rel risk | 1.61 | 1.40 | 1.85
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | 9) Cesarean delivery in singletons only:
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | C/S + | C/S - | Total
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | ICSI | 689 | 1093 | 1782
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Natural | 1366 | 6768 | 8134
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | Total | 2055 | 7861 | 9916
Katalinic, Rosch, Ludwig, et al., 2004 #13020 | Geographical location: Germany Study dates: 1993 - 2001 Size of population: 3,372 ICSI, 8,016 natural conception Study type: Cohort study | | Definition(s) of outcome(s): Major malformations Secondary outcomes = maternal complications PTB < 37wks Preeclampsia (Pre-X) > 140/90 BP + proteinuria > 300 mg | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 2.30 | 2.13 | 2.48
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | 1) Adjusted OR*, singleton pregnancies, ART vs non-ART, 1998-1999: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period:+ Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | OUTCOME | OR | 95% CI
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | Maternal
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | Antepartum hospitalization | 2.23 | 2.03,2.46
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | >7 days in hospital | 1.37 | 1.11,1.70
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | C-section | 1.30 | 1.17,1.45
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | Neonatal
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | Weigh < 2500 gm | 1.70 | 1.39,2.09
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | Gest age <37 weeks | 1.79 | 1.52,2.11
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | 1 min Apgar 0–6 | 1.35 | 1.11,1.65
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | >7 days in hospital | 1.86 | 1.60,2.16
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | Perinatal mortality | 1.27 | 0.59,2.70
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | *Adjusted for county of residence, smoking, age, marital status, previous pregnancies, previous deliveries 2) Adjusted OR*, multiple gestations, ART vs non-ART, 1998-1999:
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | OUTCOME | OR | 95% CI
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | Maternal
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | Antepartum hospitalization | 1.66 | 1.31,2.10
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | >7 days in hospital | 1.02 | 0.78,1.34
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | C-section | 1.12 | 0.89,1.40
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | Neonatal
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | Weigh < 2500 gm | 1.12 | 0.96,1.31
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | Gest age <37 weeks | 1.45 | 1.24,1.68
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | 1 min Apgar 0–6 | 1.23 | 0.99,1.54
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | >7 days in hospital | 1.24 | 1.04,1.44
Klemetti, Gissler, and Hemminki, 2002 #1330 | Geographical location: Finland Study dates: 1991-1993; 1998-1999 Size of population (no. of patients): All births in each time period Study type: Cohort | Age: 1998-1999: IVF: 39.3% ≥ 35 Non-IVF: 17.3% ≥ 35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All births in Finland Exclusion criteria: None | Definition(s) of outcome(s): Single pregnancies Multiple gestations | Perinatal mortality | 0.84 | 0.40,1.75
*Adjusted for county of residence, smoking, age, marital status, previous pregnancies, previous deliveries 3) Risks for all outcomes decreased from 1991-1993 to 1998-1999, largely due to decrease in higher-order multiples.
Klemetti, Gissler, Sevon, et al. 2005 #39840 | Geographical location: Oulu, Finland Study dates: ART 1996 - 1998 Size of population: IVF 4,559, other ART 4,467, controls 27,078 Study type: Case-control Register-based; identified cases (conceived by ART) then randomly selected controls (naturally-conceived) in 3:1 ratio | Age: Mean (SD): IVF 33.9 (4.5) Other ART 31.2 (4.6) Controls 29.8 (5.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Cases: Children born to women after ART 1996 - 1998 in Finland. Controls: naturally-conceived children randomly selected from Medical Birth Register Exclusion criteria: Controls excluded those conceived through IVF or other ART | Definition(s) of outcome(s): Cases & controls linked to Finnish Register of Congenital Malformations (collects info on all infants with congenital anomaly or birth defect through delivery info, neonatal, pedi, and path depts., and cytogenetic labs, and by linkage to other national registers. Congenital anomaly = major congenital structural anomaly, chromosomal defect, or congenital hypothyroidism. Physician reviewed Dx blinded to mode of conception. | 1) Any congenital anomaly, IVF singletons: | | | | Comments:; - ART moms more often married, nulliparous, upper class.; - More multiples in ART grps.; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: + Comparability of cases and controls with respect to potential confounders: - Validated dietary assessment method: NR Appropriateness of statistical analyses: - (not adjusted by potential confounders)
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | | anom+ | anom- | Total
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | IVF | 125 | 2805 | 2930
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Ctrl | 756 | 25733 | 26489
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Total | 881 | 28538 | 29419
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | | Value | Lower 95% CI | Upper 95% CI
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Odds rat | 1.52 | 1.25 | 1.84
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Other art singletons:
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | | anom+ | anom- | Total
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | other | 138 | 3788 | 3926
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Ctrl | 756 | 25733 | 26489
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Total | 894 | 29521 | 30415
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | | Value | Lower 95% CI | Upper 95% CI
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Odds rat | 1.24 | 1.03 | 1.49
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | IVF multiples:
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | | anom+ | anom- | Total
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | IVF | 70 | 1559 | 1629
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Ctrl | 31 | 558 | 589
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Total | 101 | 2117 | 2218
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | | Value | Lower 95% CI | Upper 95% CI
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Odds rat | 0.81 | 0.52 | 1.25
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Other art multiples:
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | | anom+ | anom- | Total
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Other | 27 | 514 | 541
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Ctrl | 31 | 558 | 589
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Total | 58 | 1072 | 1130
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | | Value | Lower 95% CI | Upper 95% CI
Klemetti, Gissler, Sevon, et al. 2005 #39840 | | | | Odds rat | 0.95 | 0.56 | 1.61
Data given also by organ system, and by gender.
Klip, Burger, de Kraker, et al., 2001 #3670 | Geographical location: Amsterdam, Netherlands Study dates: Women in cohort diagnosed 1980 - 1995 Size of population: 9,479 cases, 7,521 controls Study type: Cohort of women with infertility in registry, mailed questionnaire to assess for cancer in offspring | Age: Mean (SD): given as categorical ranges Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Original cohort of women unable to achieve conception after >=1yr, >18yo at first visit to fertility clinic. Of these, women alive on 1/1/97 were mailed questionnaire. Eligible offspring were >=26wks or 1000g. Exposed = conceived by IVF, insemination, fertility drug use. Control = no IVF. Exclusion criteria: From questionnaire: Death, incomplete or foreign address, emigration, privacy reason Excluded from pregnancies: miscarriages, stillbirths, not yet born at time of interview, unknown gender, unknown birthdate, unknown exposure status. | Definition(s) of outcome(s): CA in offspring of ART conceptions Average f/u was 6yr (4.6yr in exposed, 7.8yr in ctrl) | 1) Any CA: | | | | Comments:; - Response rate 66.9%; - Open-ended questions, not specific to cancer; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: - Analysis (multivariate adjustments) and reporting of results: +
Klip, Burger, de Kraker, et al., 2001 #3670 | | | Definition(s) of outcome(s): CA in offspring of ART conceptions Average f/u was 6yr (4.6yr in exposed, 7.8yr in ctrl) | | CA+ | CA- | Total
Klip, Burger, de Kraker, et al., 2001 #3670 | | | Definition(s) of outcome(s): CA in offspring of ART conceptions Average f/u was 6yr (4.6yr in exposed, 7.8yr in ctrl) | Observed | 7 | 9465 | 9472
Klip, Burger, de Kraker, et al., 2001 #3670 | | | Definition(s) of outcome(s): CA in offspring of ART conceptions Average f/u was 6yr (4.6yr in exposed, 7.8yr in ctrl) | Expected | 7.1 | 9464.9 | 9472
Klip, Burger, de Kraker, et al., 2001 #3670 | | | Definition(s) of outcome(s): CA in offspring of ART conceptions Average f/u was 6yr (4.6yr in exposed, 7.8yr in ctrl) | Total | 14.1 | 18929.9 | 18944
Klip, Burger, de Kraker, et al., 2001 #3670 | | | Definition(s) of outcome(s): CA in offspring of ART conceptions Average f/u was 6yr (4.6yr in exposed, 7.8yr in ctrl) | | Value | Lower 95% CI | Upper 95% CI
Klip, Burger, de Kraker, et al., 2001 #3670 | | | Definition(s) of outcome(s): CA in offspring of ART conceptions Average f/u was 6yr (4.6yr in exposed, 7.8yr in ctrl) | Odds rat | 0.99 | 0.35 | 2.80
Klip, Burger, de Kraker, et al., 2001 #3670 | | | Definition(s) of outcome(s): CA in offspring of ART conceptions Average f/u was 6yr (4.6yr in exposed, 7.8yr in ctrl) | 2) Leukemia:
Klip, Burger, de Kraker, et al., 2001 #3670 | | | Definition(s) of outcome(s): CA in offspring of ART conceptions Average f/u was 6yr (4.6yr in exposed, 7.8yr in ctrl) | | leuk+ | leuk- | Total
Klip, Burger, de Kraker, et al., 2001 #3670 | | | Definition(s) of outcome(s): CA in offspring of ART conceptions Average f/u was 6yr (4.6yr in exposed, 7.8yr in ctrl) | Observed | 3 | 9469 | 9472
Klip, Burger, de Kraker, et al., 2001 #3670 | | | Definition(s) of outcome(s): CA in offspring of ART conceptions Average f/u was 6yr (4.6yr in exposed, 7.8yr in ctrl) | Expected | 2.3 | 9469.7 | 9472
Klip, Burger, de Kraker, et al., 2001 #3670 | | | Definition(s) of outcome(s): CA in offspring of ART conceptions Average f/u was 6yr (4.6yr in exposed, 7.8yr in ctrl) | Total | 5.3 | 18938.7 | 18944
Klip, Burger, de Kraker, et al., 2001 #3670 | | | Definition(s) of outcome(s): CA in offspring of ART conceptions Average f/u was 6yr (4.6yr in exposed, 7.8yr in ctrl) | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.30 | 0.23 | 7.27
Koivurova, Hartikainen, Gissler, et al. 2002 #2150 | Geographical location: Oulu, Finland Study dates: 1990 - 95 Size of population: 304 IVF, 569 controls, 103 twin controls Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Register of IVF clinic at 2 centers which cover all IVF in northern Finland provided study grp. 2 control grps: I - chosen at random from Finnish Med Birth Register, matched for sex, yr of birth, area of residence, parity, mat age, social class II - multiples randomly chosen and matched as above Exclusion criteria: No triplets & quads for matching available; excluded for analysis stratified for plurality, but included in population-based analyses | Definition(s) of outcome(s): 3yr f/u of records Perinatal mortality rate includes stillbirths from >22wks or BW >=500g. Early neonatal mortality = neonatal deaths <7d from birth Late neonatal mort 7–27d Mortality rates compared with national figures from FMBR for northern Finland | 1) Preterm birth <3 7wks: | | | | Comments: Trips/quads not matched for but still included in population-based analyses Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Koivurova, Hartikainen, Gissler, et al. 2002 #2150 | Geographical location: Oulu, Finland Study dates: 1990 - 95 Size of population: 304 IVF, 569 controls, 103 twin controls Study type: Cohort | | | | PTB+ | PTB- | Total
Koivurova, Hartikainen, Gissler, et al. 2002 #2150 | Geographical location: Oulu, Finland Study dates: 1990 - 95 Size of population: 304 IVF, 569 controls, 103 twin controls Study type: Cohort | | | IVF | 95 | 209 | 304
Koivurova, Hartikainen, Gissler, et al. 2002 #2150 | Geographical location: Oulu, Finland Study dates: 1990 - 95 Size of population: 304 IVF, 569 controls, 103 twin controls Study type: Cohort | | | Ctrl I | 44 | 525 | 569
Koivurova, Hartikainen, Gissler, et al. 2002 #2150 | Geographical location: Oulu, Finland Study dates: 1990 - 95 Size of population: 304 IVF, 569 controls, 103 twin controls Study type: Cohort | | | Total | 139 | 734 | 873
Koivurova, Hartikainen, Gissler, et al. 2002 #2150 | Geographical location: Oulu, Finland Study dates: 1990 - 95 Size of population: 304 IVF, 569 controls, 103 twin controls Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Koivurova, Hartikainen, Gissler, et al. 2002 #2150 | Geographical location: Oulu, Finland Study dates: 1990 - 95 Size of population: 304 IVF, 569 controls, 103 twin controls Study type: Cohort | | | Odds rat | 5.42 | 3.67 | 8.02
Koivurova, Hartikainen, Gissler, et al. 2002 #2150 | Geographical location: Oulu, Finland Study dates: 1990 - 95 Size of population: 304 IVF, 569 controls, 103 twin controls Study type: Cohort | | | But significance disappears when comparing singletons to sing & twins to twins 2) Major malformations:
Koivurova, Hartikainen, Gissler, et al. 2002 #2150 | Geographical location: Oulu, Finland Study dates: 1990 - 95 Size of population: 304 IVF, 569 controls, 103 twin controls Study type: Cohort | | | | Malf+ | Malf- | Total
Koivurova, Hartikainen, Gissler, et al. 2002 #2150 | Geographical location: Oulu, Finland Study dates: 1990 - 95 Size of population: 304 IVF, 569 controls, 103 twin controls Study type: Cohort | | | IVF | 20 | 284 | 304
Koivurova, Hartikainen, Gissler, et al. 2002 #2150 | Geographical location: Oulu, Finland Study dates: 1990 - 95 Size of population: 304 IVF, 569 controls, 103 twin controls Study type: Cohort | | | Ctrl I | 25 | 544 | 569
Koivurova, Hartikainen, Gissler, et al. 2002 #2150 | Geographical location: Oulu, Finland Study dates: 1990 - 95 Size of population: 304 IVF, 569 controls, 103 twin controls Study type: Cohort | | | Total | 45 | 828 | 873
Koivurova, Hartikainen, Gissler, et al. 2002 #2150 | Geographical location: Oulu, Finland Study dates: 1990 - 95 Size of population: 304 IVF, 569 controls, 103 twin controls Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.53 | 0.84 | 2.81
Koivurova, Hartihainen, Karinen, et al., 2002 #770 | Geographical location: Oulu, Finland Study dates: 1990-95 Size of population: 305 IVF, 671 Controls Study type: Cohort | Age: Mean: IVF: 31.8 Controls: 31.8 Range: IVF: 23–40 Controls: 19–40 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 25% Male factor: 16% Tubal factor: 41% Endometriosis, mixed, hormonal: 17% Inclusion criteria:; - IVF pregnancies from registers of 2 clinics covering all IVF pregnancies in northern Finland > 22 wk or = 500 g; - Controls chosen from FMBR as in previous study; I = general population, II = matched for plurality; Exclusion criteria:; - < 22 wk; - < 500 g | Definition(s) of outcome(s): Gestational HTN = BP 140/90 or 30/15 Preex > 300 mg prot/24h Threatened preterm birth = ctxs w/or w/o cvx change requiring hospitalization | 1) Threatened PTB, singletons: | | | | Comments: Data obtained from same source for both groups (FMBR) Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: NR Completeness of follow-up: NR Analysis (multivariate adjustments) and reporting of results: +
Koivurova, Hartihainen, Karinen, et al., 2002 #770 | Geographical location: Oulu, Finland Study dates: 1990-95 Size of population: 305 IVF, 671 Controls Study type: Cohort | | Definition(s) of outcome(s): Gestational HTN = BP 140/90 or 30/15 Preex > 300 mg prot/24h Threatened preterm birth = ctxs w/or w/o cvx change requiring hospitalization | | Threat PTB + | Threat PTB - | Total
Koivurova, Hartihainen, Karinen, et al., 2002 #770 | Geographical location: Oulu, Finland Study dates: 1990-95 Size of population: 305 IVF, 671 Controls Study type: Cohort | | Definition(s) of outcome(s): Gestational HTN = BP 140/90 or 30/15 Preex > 300 mg prot/24h Threatened preterm birth = ctxs w/or w/o cvx change requiring hospitalization | IVF | 22 | 131 | 153
Koivurova, Hartihainen, Karinen, et al., 2002 #770 | Geographical location: Oulu, Finland Study dates: 1990-95 Size of population: 305 IVF, 671 Controls Study type: Cohort | | Definition(s) of outcome(s): Gestational HTN = BP 140/90 or 30/15 Preex > 300 mg prot/24h Threatened preterm birth = ctxs w/or w/o cvx change requiring hospitalization | Ctrl | 47 | 533 | 580
Koivurova, Hartihainen, Karinen, et al., 2002 #770 | Geographical location: Oulu, Finland Study dates: 1990-95 Size of population: 305 IVF, 671 Controls Study type: Cohort | | Definition(s) of outcome(s): Gestational HTN = BP 140/90 or 30/15 Preex > 300 mg prot/24h Threatened preterm birth = ctxs w/or w/o cvx change requiring hospitalization | Total | 69 | 664 | 733
Koivurova, Hartihainen, Karinen, et al., 2002 #770 | Geographical location: Oulu, Finland Study dates: 1990-95 Size of population: 305 IVF, 671 Controls Study type: Cohort | | Definition(s) of outcome(s): Gestational HTN = BP 140/90 or 30/15 Preex > 300 mg prot/24h Threatened preterm birth = ctxs w/or w/o cvx change requiring hospitalization | | Value | Lower 95% CI | Upper 95% CI
Koivurova, Hartihainen, Karinen, et al., 2002 #770 | Geographical location: Oulu, Finland Study dates: 1990-95 Size of population: 305 IVF, 671 Controls Study type: Cohort | | Definition(s) of outcome(s): Gestational HTN = BP 140/90 or 30/15 Preex > 300 mg prot/24h Threatened preterm birth = ctxs w/or w/o cvx change requiring hospitalization | Odds rat | 1.90 | 1.11 | 3.27
Koivurova, Hartihainen, Karinen, et al., 2002 #770 | Geographical location: Oulu, Finland Study dates: 1990-95 Size of population: 305 IVF, 671 Controls Study type: Cohort | | Definition(s) of outcome(s): Gestational HTN = BP 140/90 or 30/15 Preex > 300 mg prot/24h Threatened preterm birth = ctxs w/or w/o cvx change requiring hospitalization | 2) Threatened PTB, twins:
Koivurova, Hartihainen, Karinen, et al., 2002 #770 | Geographical location: Oulu, Finland Study dates: 1990-95 Size of population: 305 IVF, 671 Controls Study type: Cohort | | Definition(s) of outcome(s): Gestational HTN = BP 140/90 or 30/15 Preex > 300 mg prot/24h Threatened preterm birth = ctxs w/or w/o cvx change requiring hospitalization | | Threat PTB + | Threat PTB - | Total
Koivurova, Hartihainen, Karinen, et al., 2002 #770 | Geographical location: Oulu, Finland Study dates: 1990-95 Size of population: 305 IVF, 671 Controls Study type: Cohort | | Definition(s) of outcome(s): Gestational HTN = BP 140/90 or 30/15 Preex > 300 mg prot/24h Threatened preterm birth = ctxs w/or w/o cvx change requiring hospitalization | IVF | 23 | 39 | 62
Koivurova, Hartihainen, Karinen, et al., 2002 #770 | Geographical location: Oulu, Finland Study dates: 1990-95 Size of population: 305 IVF, 671 Controls Study type: Cohort | | Definition(s) of outcome(s): Gestational HTN = BP 140/90 or 30/15 Preex > 300 mg prot/24h Threatened preterm birth = ctxs w/or w/o cvx change requiring hospitalization | Ctrl | 36 | 46 | 82
Koivurova, Hartihainen, Karinen, et al., 2002 #770 | Geographical location: Oulu, Finland Study dates: 1990-95 Size of population: 305 IVF, 671 Controls Study type: Cohort | | Definition(s) of outcome(s): Gestational HTN = BP 140/90 or 30/15 Preex > 300 mg prot/24h Threatened preterm birth = ctxs w/or w/o cvx change requiring hospitalization | Total | 59 | 85 | 144
Koivurova, Hartihainen, Karinen, et al., 2002 #770 | Geographical location: Oulu, Finland Study dates: 1990-95 Size of population: 305 IVF, 671 Controls Study type: Cohort | | Definition(s) of outcome(s): Gestational HTN = BP 140/90 or 30/15 Preex > 300 mg prot/24h Threatened preterm birth = ctxs w/or w/o cvx change requiring hospitalization | | Value | Lower 95% CI | Upper 95% CI
Koivurova, Hartihainen, Karinen, et al., 2002 #770 | Geographical location: Oulu, Finland Study dates: 1990-95 Size of population: 305 IVF, 671 Controls Study type: Cohort | | Definition(s) of outcome(s): Gestational HTN = BP 140/90 or 30/15 Preex > 300 mg prot/24h Threatened preterm birth = ctxs w/or w/o cvx change requiring hospitalization | Odds rat | 0.75 | 0.38 | 1.48
C/S rates 25% in both IVF and control groups for singletons For firstborn twins, 53% (IVF), 46% (controls)
Kolibianakis, Osmanagaoglu, De Catte, et al., 2003 #17460 | Geographical location: Brussels, Belgium Study dates: 1992 - 2000 Size of population: 685 amnio, 143 CVSs Study type: Case-control Compared outcomes of ICSI pregnancies in which amniocentesis was performed, to those in which CVS was performed. | Age: Mean (SD): Amnio - 32.4 (0.2) CVS - 33.8 (0.4) Median: NR Range: Amnio - 20–47 CVS - 22–50 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: See study type Exclusion criteria: NR | Definition(s) of outcome(s): Preterm delivery (< 37w) Low birthwt (< 2500g) VLBW (< 1500g) Fetal loss | 1) CVS vs amnio as risk for fetal loss in ICSO population: | | | | Comments:; - Not possible to randomize choice of procedure.; - Maternal age lower in amnio grp compared to CVS.; CVS known to have higher loss rate than amnio. Would not expect difference in ICSI population.; - Even so, this loss rate is higher than other series (most report loss rate for CVS of 1%, compared to 3% in this series), for amnio of 0.5%, compared to 0.9% in this series.; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: - Appropriateness of the control population: + Verification that the control is free of cancer: n/a Comparability of cases and controls with respect to potential confounders: - Validated dietary assessment method: - Appropriateness of statistical analyses: +
Kolibianakis, Osmanagaoglu, De Catte, et al., 2003 #17460 | | | Definition(s) of outcome(s): Preterm delivery (< 37w) Low birthwt (< 2500g) VLBW (< 1500g) Fetal loss | | Fetal loss+ | Fetal loss - | Total
Kolibianakis, Osmanagaoglu, De Catte, et al., 2003 #17460 | | | Definition(s) of outcome(s): Preterm delivery (< 37w) Low birthwt (< 2500g) VLBW (< 1500g) Fetal loss | CVS | 5 | 130 | 135
Kolibianakis, Osmanagaoglu, De Catte, et al., 2003 #17460 | | | Definition(s) of outcome(s): Preterm delivery (< 37w) Low birthwt (< 2500g) VLBW (< 1500g) Fetal loss | Amnio | 6 | 674 | 680
Kolibianakis, Osmanagaoglu, De Catte, et al., 2003 #17460 | | | Definition(s) of outcome(s): Preterm delivery (< 37w) Low birthwt (< 2500g) VLBW (< 1500g) Fetal loss | Total | 11 | 804 | 815
Kolibianakis, Osmanagaoglu, De Catte, et al., 2003 #17460 | | | Definition(s) of outcome(s): Preterm delivery (< 37w) Low birthwt (< 2500g) VLBW (< 1500g) Fetal loss | | Value | Lower 95% CI | Upper 95% CI
Kolibianakis, Osmanagaoglu, De Catte, et al., 2003 #17460 | | | Definition(s) of outcome(s): Preterm delivery (< 37w) Low birthwt (< 2500g) VLBW (< 1500g) Fetal loss | Odds rat | 4.32 | 1.30 | 14.37
No sig diff in PTD rate, LBW, or VLBW
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | Age: Mean (SD): IVF 32.8 (4.3) Control: 32.7 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Pregnancies > 16 wk; IVF pregnancies established before end of 1992, with prenatal care at hospital that performed the procedure.; - Controls from registry of same hospital, matched for LMP w/I 2 yr, parity, ethnic origin, del date w/I 2 yr of case, height (w/i 10 cm), weight (w/I 10 kg), smoking status, ob & med hx for “factors that might influence outcome of subsequent pregnancy”; Exclusion criteria:; - FET, reductions, IVF pregnancies for whom no suitable control could be found; - Did not exclude pregnancies w/vanishing twin | Definition(s) of outcome(s): SGA = birthwt < 10%ile for national reference curve LBW < 2500 g Stillbirth ≥ 500 g Neonatal death 7 d Perinatal mortality = IUFD + neonatal deaths / Total live + stillbirths | No diff in PIH, hyperemesis, GDM, poly, abruption, PPROM, FGR, previa, malformations. Raw data not given, but VB more common in IVF grp: 1^st^ trim 21.2% vs 13.7% 2^nd^ trim 7.8% vs 2.0% 3^rd^ trim 8.6% vs 3.9% IVF pts spent more days on admission in hosp than controls (4.6 ± 10.2 vs 2.5 ± 5.4) Raw data not given for these, only %: 1) Elective (non-labored) C/S: | | | | Comments: Similar weight, height, BMI, cigarette use, EtOH use, primiparity, h/o PTD, congenital malformations, IUFD, neonatal mortality, C/S, PIH, GDM between groups. Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): Large sample size: Adequate description of the cohort: Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: Adequate follow-up period: NR Completeness of follow-up: NR Analysis (multivariate adjustments) and reporting of results:
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | | C/S + | C/S -
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | IVF | 27 | 280 | 307
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | Control | 13 | 294 | 307
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | | 40 | 574 | 614
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | | | Lower 95% CI | Upper 95 % CI
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | Rel risk | 2.08 | 1.09 | 3.95
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | 2) LBW:
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | | LBW + | LBW -
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | IVF | 42 | 265 | 307
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | Control | 21 | 286 | 307
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | | 63 | 551 | 614
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | | | Lower 95% CI | Upper 95 % CI
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | Rel risk | 2 | 1.21 | 3.30
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | 3) PTD:
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | | Preg + | Preg -
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | Study drug | 46 | 261 | 307
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | Control | 18 | 289 | 307
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | | 64 | 550 | 614
Koudstaal, Braat, Bruinse, et al., 2000 #7340 | Geographical location: Amsterdam, Netherlands Study dates: NR (care established before end of 1992; published 2000) Size of population: 307 IVF, 307 control pregnancies Study type: Cohort | | | | | Lower 95% CI | Upper 95 % CI
Rel risk | 2.56 | 1.52 | 4.30
Koudstaal, Bruinse, Helmerhorst, et al. 2000 #8180 | Geographical location: Amsterdam, Netherlands Study dates: IVF preg established before end of 1992 (published 2000) Size of population: 96 IVF, 96 ctrl Study type: Case-control | Age: Mean (SD): IVF 31.7 (3.6), ctrl 31.2 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Pregnancies >16wks; IVF pregnancies established before end of 1992, with prenatal care at hospital that performed the procedure. Ctrls from registry of same hospital as cases, matched for mat age, parity, ethnic origin, del dat w/I 3yr, ht, wt, smoking status, prenatal care site Exclusion criteria: FET, reductions | Definition(s) of outcome(s): PTD < 37wks SGA < 10%ile by national reference curve LBW > 500g and ≤ 2500g Stillbirth ≥ 500g Neonatal death = death of liveborn ≥ 500g within 1^st^ wk after birth C/S elective if performed before labor | No difference in PIH, GDM, previa, PPROM, ut ctxs, elective C/S, induction perinatal mortality, congenital malformations. Raw data not shown, but vaginal bleeding more common in IVF (32.3% vs 18.8%) 1) PTD: | | | | Comments:; - No mention of matching for ob/med hx as in singleton study from this grp.; - Similar parity, h/o PTD, IUFD, PIH, C/S; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: + Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Koudstaal, Bruinse, Helmerhorst, et al. 2000 #8180 | Geographical location: Amsterdam, Netherlands Study dates: IVF preg established before end of 1992 (published 2000) Size of population: 96 IVF, 96 ctrl Study type: Case-control | | | | PTD+ | PTD- | Total
Koudstaal, Bruinse, Helmerhorst, et al. 2000 #8180 | Geographical location: Amsterdam, Netherlands Study dates: IVF preg established before end of 1992 (published 2000) Size of population: 96 IVF, 96 ctrl Study type: Case-control | | | IVF | 49 | 47 | 96
Koudstaal, Bruinse, Helmerhorst, et al. 2000 #8180 | Geographical location: Amsterdam, Netherlands Study dates: IVF preg established before end of 1992 (published 2000) Size of population: 96 IVF, 96 ctrl Study type: Case-control | | | Ctrl | 40 | 56 | 96
Koudstaal, Bruinse, Helmerhorst, et al. 2000 #8180 | Geographical location: Amsterdam, Netherlands Study dates: IVF preg established before end of 1992 (published 2000) Size of population: 96 IVF, 96 ctrl Study type: Case-control | | | Total | 89 | 103 | 192
Koudstaal, Bruinse, Helmerhorst, et al. 2000 #8180 | Geographical location: Amsterdam, Netherlands Study dates: IVF preg established before end of 1992 (published 2000) Size of population: 96 IVF, 96 ctrl Study type: Case-control | | | | Value | Lower 95% CI | Upper 95% CI
Koudstaal, Bruinse, Helmerhorst, et al. 2000 #8180 | Geographical location: Amsterdam, Netherlands Study dates: IVF preg established before end of 1992 (published 2000) Size of population: 96 IVF, 96 ctrl Study type: Case-control | | | Odds rat | 1.46 | 0.83 | 2.58
Koudstaal, Bruinse, Helmerhorst, et al. 2000 #8180 | Geographical location: Amsterdam, Netherlands Study dates: IVF preg established before end of 1992 (published 2000) Size of population: 96 IVF, 96 ctrl Study type: Case-control | | | 2) C/S per child:
Koudstaal, Bruinse, Helmerhorst, et al. 2000 #8180 | Geographical location: Amsterdam, Netherlands Study dates: IVF preg established before end of 1992 (published 2000) Size of population: 96 IVF, 96 ctrl Study type: Case-control | | | | PTD+ | PTD- | Total
Koudstaal, Bruinse, Helmerhorst, et al. 2000 #8180 | Geographical location: Amsterdam, Netherlands Study dates: IVF preg established before end of 1992 (published 2000) Size of population: 96 IVF, 96 ctrl Study type: Case-control | | | IVF | 77 | 115 | 192
Koudstaal, Bruinse, Helmerhorst, et al. 2000 #8180 | Geographical location: Amsterdam, Netherlands Study dates: IVF preg established before end of 1992 (published 2000) Size of population: 96 IVF, 96 ctrl Study type: Case-control | | | Ctrl | 59 | 133 | 192
Koudstaal, Bruinse, Helmerhorst, et al. 2000 #8180 | Geographical location: Amsterdam, Netherlands Study dates: IVF preg established before end of 1992 (published 2000) Size of population: 96 IVF, 96 ctrl Study type: Case-control | | | Total | 136 | 248 | 384
Koudstaal, Bruinse, Helmerhorst, et al. 2000 #8180 | Geographical location: Amsterdam, Netherlands Study dates: IVF preg established before end of 1992 (published 2000) Size of population: 96 IVF, 96 ctrl Study type: Case-control | | | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.51 | 0.99 | 2.30
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | Geographical location: Szeged, Hungary Study dates: Jan 1995 – Dec 2001 Size of population: 376 pregnancies after ART, 12,920 deliveries total Study type: Case-control Pregnancies conceived by ART, controls conceived spontaneously matched 1:1 by G/P, maternal age, previous obstetric outcome. | Age: Mean (SD): ART - 32.3 (4) Spont - 32.0 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at one hospital during study period Exclusion criteria: Triplet pregnancies (IVF 12, OI 5) were analyzed w/o spontaneous controls. No other exclusions reported | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | No diff in any outcome except slightly lower birthweight for spontaneous twins 1) Cesarean for singletons: | | | | Comments: None Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: + Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | | C/S + | C/S - | Total
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | ART | 117 | 167 | 284
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | Spont | 98 | 186 | 284
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | Total | 215 | 353 | 568
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | | Value | Lower 95% CI | Upper 95% CI
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | Odds rat | 1.33 | 0.95 | 1.87
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | 2) FGR for singletons:
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | | FGR+ | FGR - | Total
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | ART | 18 | 266 | 284
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | Spont | 12 | 272 | 284
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | Total | 30 | 538 | 568
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | | Value | Lower 95% CI | Upper 95% CI
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | Odds rat | 1.53 | 0.72 | 3.25
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | 3) Major malformations for singletons:
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | | Maj malform+ | Maj malform - | Total
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | ART | 9 | 275 | 284
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | Spont | 5 | 279 | 284
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | Total | 14 | 554 | 568
Kozinszky, Zadori, Orvos, et al. 2003 #15900 | | | Definition(s) of outcome(s): IUGR defined as birthwt <10^th^ %ile for GA, according to Hungarian data | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.83 | 0.60 | 5.52
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | Geographical location: Szeged, Hungary Study dates: Jan 1995–May 2001 Size of population: 259 ART, 518 controls Study type: Case-control ART pregnancies (ART = mix of IVF, OI, and IUI) identified, compared to matched controls, presumably during same study period | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Live, singleton pregnancies resulting from ART; - Controls spontaneously conceived, matched for G, P, maternal age (2:1); Exclusion criteria: NR | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | 1) Cesarean section: | | | | Comments:; - ART group more likely to have GDM than controls; - No info regarding planned vs unplanned cesarean, or indications; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: + Comparability of cases and controls with respect to potential confounders: + Validated dietary assessment method: NR Appropriateness of statistical analyses: - (no multivariate adjustments)
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | | CS + | CS - | Total
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | ART | 110 | 149 | 259
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | Ctrl | 143 | 375 | 518
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | Total | 253 | 524 | 777
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | | Value | Lower 95% CI | Upper 95% CI
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | Odds rat | 1.94 | 1.42 | 2.65
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | 2) Congenital malformations:
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | | Malf + | Malf - | Total
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | ART | 7 | 252 | 259
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | Ctrl | 13 | 505 | 518
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | Total | 20 | 757 | 777
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | | Value | Lower 95% CI | Upper 95% CI
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | Odds rat | 1.08 | 0.43 | 2.74
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | 3) Preeclampsia:
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | | Preex + | Preex - | Total
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | ART | 45 | 214 | 259
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | Ctrl | 58 | 460 | 518
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | Total | 103 | 674 | 777
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | | Value | Lower 95% CI | Upper 95% CI
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | Odds rat | 1.67 | 1.09 | 2.54
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | 4) Preterm birth:
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | | PTB + | PTB - | Total
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | ART | 33 | 226 | 259
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | Ctrl | 57 | 461 | 518
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | Total | 90 | 687 | 777
Kozinszky, Zadori, Orvos, et al., 2003 #16940 | | | Definition(s) of outcome(s): Congenital malformations diagnosed by neonatologist Preeclampsia not defined | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.18 | 0.75 | 1.87
Kristiansson, Bjor, and Wramsby, 2007 #53260 | Geographical location: Sweden Study dates: Registered for 1^st^ birth between Jan 1981–Dec 2001 Size of population (no. of patients): 647,704 Study type: Cohort | Age: Mean (SD) age at conception: IVF: 32.8 (3.7) Non-IVF: 26.7 (4.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Registered for 1^st^ birth during study period; - Exposure: Treated with IVF/ICSI; Exclusion criteria: NR | Definition(s) of outcome(s): Cancer cases from Swedish national registry | 1) Adjusted* rate ratios, date of conception plus 3 years used as start of followup: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Kristiansson, Bjor, and Wramsby, 2007 #53260 | Geographical location: Sweden Study dates: Registered for 1^st^ birth between Jan 1981–Dec 2001 Size of population (no. of patients): 647,704 Study type: Cohort | | Definition(s) of outcome(s): Cancer cases from Swedish national registry | | RR | 95% CI
Kristiansson, Bjor, and Wramsby, 2007 #53260 | Geographical location: Sweden Study dates: Registered for 1^st^ birth between Jan 1981–Dec 2001 Size of population (no. of patients): 647,704 Study type: Cohort | | Definition(s) of outcome(s): Cancer cases from Swedish national registry | CIS of cervix | 0.86 | 0.60–1.19
Kristiansson, Bjor, and Wramsby, 2007 #53260 | Geographical location: Sweden Study dates: Registered for 1^st^ birth between Jan 1981–Dec 2001 Size of population (no. of patients): 647,704 Study type: Cohort | | Definition(s) of outcome(s): Cancer cases from Swedish national registry | All non-invasive | 0.87 | 0.64–1.16
Kristiansson, Bjor, and Wramsby, 2007 #53260 | Geographical location: Sweden Study dates: Registered for 1^st^ birth between Jan 1981–Dec 2001 Size of population (no. of patients): 647,704 Study type: Cohort | | Definition(s) of outcome(s): Cancer cases from Swedish national registry | Breast | 0.74 | 0.40–1.26
Kristiansson, Bjor, and Wramsby, 2007 #53260 | Geographical location: Sweden Study dates: Registered for 1^st^ birth between Jan 1981–Dec 2001 Size of population (no. of patients): 647,704 Study type: Cohort | | Definition(s) of outcome(s): Cancer cases from Swedish national registry | All invasive | 1.00 | 0.71–1.36
*Adjusted for age at followup, age at first conception, calendar year at followup, number of parities and multiple births. 2) CIS of cervix significantly lower in IVF subjects when date of conception used as start of followup (0.7, 95% CI 0.52, 0.92).
Kuwata, Matsubara, Ohkuchi, et al., 2004 #11910 | Geographical location: Tochigi, Japan Study dates: Jan 1990–July 2001 Size of population (no. of patients): 406 (94 spontaneous) Study type: Cohort | Age: Mean (SD): Median: 29.5 spontaneous, 30.5 ovulation induction, 31.5–34.5 ART Range: Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Dichorionic twin gestation followed at hospital; - Delivery at ≥24 weeks; Exclusion criteria:; - Referred after 20 weeks or referred for malformation; - Frozen embryo transfer | Definition(s) of outcome(s): Congenital anomalies (ICD-10) | 1) Adjusted odds ratios (adjusted for maternal age only): | | | | Comments:; - Potential for referral bias—unclear what criterion were for referral; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Kuwata, Matsubara, Ohkuchi, et al., 2004 #11910 | Geographical location: Tochigi, Japan Study dates: Jan 1990–July 2001 Size of population (no. of patients): 406 (94 spontaneous) Study type: Cohort | | Definition(s) of outcome(s): Congenital anomalies (ICD-10) | | OR | 95% CI
Kuwata, Matsubara, Ohkuchi, et al., 2004 #11910 | Geographical location: Tochigi, Japan Study dates: Jan 1990–July 2001 Size of population (no. of patients): 406 (94 spontaneous) Study type: Cohort | | Definition(s) of outcome(s): Congenital anomalies (ICD-10) | Spontaneous conception | 1.00 (ref)
Kuwata, Matsubara, Ohkuchi, et al., 2004 #11910 | Geographical location: Tochigi, Japan Study dates: Jan 1990–July 2001 Size of population (no. of patients): 406 (94 spontaneous) Study type: Cohort | | Definition(s) of outcome(s): Congenital anomalies (ICD-10) | Ovulation induction | 2.3 | 0.7,7.3
Kuwata, Matsubara, Ohkuchi, et al., 2004 #11910 | Geographical location: Tochigi, Japan Study dates: Jan 1990–July 2001 Size of population (no. of patients): 406 (94 spontaneous) Study type: Cohort | | Definition(s) of outcome(s): Congenital anomalies (ICD-10) | GIFT | 3.7 | 1.2,11.8
Kuwata, Matsubara, Ohkuchi, et al., 2004 #11910 | Geographical location: Tochigi, Japan Study dates: Jan 1990–July 2001 Size of population (no. of patients): 406 (94 spontaneous) Study type: Cohort | | Definition(s) of outcome(s): Congenital anomalies (ICD-10) | IVF | 3.5 | 1.1,11.5
ICSI | 6.7 | 2.1,21.9
La Sala, Nucera, Gallinelli et al., 2004 #12490 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 1072 ART pregnancies (440 IVF, 567 ICSI) Study type: Cohort study | Age: Mean (SD): 34.2 (4.0) Race/ethnicity (n [%]): > 95% Italian Diagnoses (n [%]): NR Inclusion criteria: Day 2–3 transfer w/o hatching Exclusion criteria: NR | Definition(s) of outcome(s): Embryo = presence of cardiac activity on US | 1) Total pregnancy loss after 2 embryos on 1^st^ trimester US, by age 35: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for genomic test: NA Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: NA Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
La Sala, Nucera, Gallinelli et al., 2004 #12490 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 1072 ART pregnancies (440 IVF, 567 ICSI) Study type: Cohort study | Age: Mean (SD): 34.2 (4.0) Race/ethnicity (n [%]): > 95% Italian Diagnoses (n [%]): NR Inclusion criteria: Day 2–3 transfer w/o hatching Exclusion criteria: NR | Definition(s) of outcome(s): Embryo = presence of cardiac activity on US | | SAb + | SAb -
La Sala, Nucera, Gallinelli et al., 2004 #12490 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 1072 ART pregnancies (440 IVF, 567 ICSI) Study type: Cohort study | Age: Mean (SD): 34.2 (4.0) Race/ethnicity (n [%]): > 95% Italian Diagnoses (n [%]): NR Inclusion criteria: Day 2–3 transfer w/o hatching Exclusion criteria: NR | Definition(s) of outcome(s): Embryo = presence of cardiac activity on US | ≥ 35 | 19 | 89 | 108
La Sala, Nucera, Gallinelli et al., 2004 #12490 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 1072 ART pregnancies (440 IVF, 567 ICSI) Study type: Cohort study | Age: Mean (SD): 34.2 (4.0) Race/ethnicity (n [%]): > 95% Italian Diagnoses (n [%]): NR Inclusion criteria: Day 2–3 transfer w/o hatching Exclusion criteria: NR | Definition(s) of outcome(s): Embryo = presence of cardiac activity on US | < 35 | 11 | 142 | 153
La Sala, Nucera, Gallinelli et al., 2004 #12490 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 1072 ART pregnancies (440 IVF, 567 ICSI) Study type: Cohort study | Age: Mean (SD): 34.2 (4.0) Race/ethnicity (n [%]): > 95% Italian Diagnoses (n [%]): NR Inclusion criteria: Day 2–3 transfer w/o hatching Exclusion criteria: NR | Definition(s) of outcome(s): Embryo = presence of cardiac activity on US | Total | 30 | 231 | 261
La Sala, Nucera, Gallinelli et al., 2004 #12490 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 1072 ART pregnancies (440 IVF, 567 ICSI) Study type: Cohort study | Age: Mean (SD): 34.2 (4.0) Race/ethnicity (n [%]): > 95% Italian Diagnoses (n [%]): NR Inclusion criteria: Day 2–3 transfer w/o hatching Exclusion criteria: NR | Definition(s) of outcome(s): Embryo = presence of cardiac activity on US | | Value | Lower 95% CI | Upper 95% CI
La Sala, Nucera, Gallinelli et al., 2004 #12490 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 1072 ART pregnancies (440 IVF, 567 ICSI) Study type: Cohort study | Age: Mean (SD): 34.2 (4.0) Race/ethnicity (n [%]): > 95% Italian Diagnoses (n [%]): NR Inclusion criteria: Day 2–3 transfer w/o hatching Exclusion criteria: NR | Definition(s) of outcome(s): Embryo = presence of cardiac activity on US | Rel risk | 2.45 | 1.21 | 4.93
La Sala, Nucera, Gallinelli et al., 2004 #12490 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 1072 ART pregnancies (440 IVF, 567 ICSI) Study type: Cohort study | Age: Mean (SD): 34.2 (4.0) Race/ethnicity (n [%]): > 95% Italian Diagnoses (n [%]): NR Inclusion criteria: Day 2–3 transfer w/o hatching Exclusion criteria: NR | Definition(s) of outcome(s): Embryo = presence of cardiac activity on US | 2) Total pregnancy loss after 1 embryo on 1^st^ trimester u/s, by age 35:
La Sala, Nucera, Gallinelli et al., 2004 #12490 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 1072 ART pregnancies (440 IVF, 567 ICSI) Study type: Cohort study | Age: Mean (SD): 34.2 (4.0) Race/ethnicity (n [%]): > 95% Italian Diagnoses (n [%]): NR Inclusion criteria: Day 2–3 transfer w/o hatching Exclusion criteria: NR | Definition(s) of outcome(s): Embryo = presence of cardiac activity on US | | SAb + | SAb -
La Sala, Nucera, Gallinelli et al., 2004 #12490 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 1072 ART pregnancies (440 IVF, 567 ICSI) Study type: Cohort study | Age: Mean (SD): 34.2 (4.0) Race/ethnicity (n [%]): > 95% Italian Diagnoses (n [%]): NR Inclusion criteria: Day 2–3 transfer w/o hatching Exclusion criteria: NR | Definition(s) of outcome(s): Embryo = presence of cardiac activity on US | ≥ 35 | 75 | 196 | 271
La Sala, Nucera, Gallinelli et al., 2004 #12490 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 1072 ART pregnancies (440 IVF, 567 ICSI) Study type: Cohort study | Age: Mean (SD): 34.2 (4.0) Race/ethnicity (n [%]): > 95% Italian Diagnoses (n [%]): NR Inclusion criteria: Day 2–3 transfer w/o hatching Exclusion criteria: NR | Definition(s) of outcome(s): Embryo = presence of cardiac activity on US | < 35 | 75 | 235 | 310
La Sala, Nucera, Gallinelli et al., 2004 #12490 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 1072 ART pregnancies (440 IVF, 567 ICSI) Study type: Cohort study | Age: Mean (SD): 34.2 (4.0) Race/ethnicity (n [%]): > 95% Italian Diagnoses (n [%]): NR Inclusion criteria: Day 2–3 transfer w/o hatching Exclusion criteria: NR | Definition(s) of outcome(s): Embryo = presence of cardiac activity on US | Total | 150 | 431 | 581
La Sala, Nucera, Gallinelli et al., 2004 #12490 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 1072 ART pregnancies (440 IVF, 567 ICSI) Study type: Cohort study | Age: Mean (SD): 34.2 (4.0) Race/ethnicity (n [%]): > 95% Italian Diagnoses (n [%]): NR Inclusion criteria: Day 2–3 transfer w/o hatching Exclusion criteria: NR | Definition(s) of outcome(s): Embryo = presence of cardiac activity on US | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.14 | 0.87 | 1.51
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | Age: Mean (SD): 34.2 (4.0) Race/ethnicity (n [%]): > 95% Italian Diagnoses (n [%]): NR Inclusion criteria: Patients undergoing IVF or ICSI Exclusion criteria: Loss to f/u or incomplete or spurious entries | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Total loss of all embryos | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | 1) Starting 4 embryos 1^st^ trimester:
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | < 35 yo | total loss+ | total loss- | Total
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | IVF | 1 | 12 | 13
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | ICSI | 1 | 10 | 11
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Total | 2 | 22 | 24
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | | Value | Lower 95% CI | Upper 95% CI
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Rel risk | 0.85 | 0.06 | 12.01
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | ≥ 35 yo | total loss+ | total loss- | Total
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | IVF | 1 | 3 | 4
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | ICSI | 1 | 5 | 6
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Total | 2 | 8 | 10
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | | Value | Lower 95% CI | Upper 95% CI
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Rel risk | 1.50 | 0.13 | 17.67
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | 2) Starting 3 embryos 1^st^ trimester:
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | < 35 yo | total loss+ | total loss- | Total
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | IVF | 2 | 26 | 28
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | ICSI | 1 | 18 | 19
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Total | 3 | 44 | 47
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | | Value | Lower 95% CI | Upper 95% CI
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Rel risk | 1.36 | 0.13 | 13.93
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | ≥ 35 yo | total loss+ | total loss- | Total
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | IVF | 2 | 20 | 22
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | ICSI | 2 | 15 | 17
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Total | 4 | 35 | 39
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | | Value | Lower 95% CI | Upper 95% CI
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Rel risk | 0.77 | 0.12 | 4.94
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | 3) Starting 2 embryos 1^st^ trimester:
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | < 35 yo | total loss+ | total loss- | Total
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | IVF | 8 | 78 | 86
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | ICSI | 3 | 64 | 67
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Total | 11 | 142 | 153
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | | Value | Lower 95% CI | Upper 95% CI
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Rel risk | 2.08 | 0.57 | 7.53
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | ≥ 35 yo | total loss+ | total loss- | Total
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | IVF | 13 | 44 | 57
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | ICSI | 6 | 45 | 51
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Total | 19 | 89 | 108
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | | Value | Lower 95% CI | Upper 95% CI
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Rel risk | 1.94 | 0.80 | 4.72
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | 4) Starting 1 embryo 1^st^ trimester:
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | < 35 yo | total loss+ | total loss- | Total
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | IVF | 40 | 120 | 160
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | ICSI | 34 | 116 | 150
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Total | 74 | 236 | 310
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | | Value | Lower 95% CI | Upper95% CI
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Rel risk | 1.10 | 0.74 | 1.64
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | ≥ 35 yo | total loss+ | total loss- | Total
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | IVF | 51 | 122 | 173
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | ICSI | 25 | 73 | 98
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | Total | 76 | 195 | 271
La Sala, Nucera, Gallinelli, et al., 2004 #11720 | Geographical location: Reggio Emilia, Italy Study dates: Jan 1992–Dec 2002 Size of population: 962 Study type: Retrospective cohort study | | Definition(s) of outcome(s): Embryonic loss rate from 1^st^ to 2^nd^ trimester as # embryos on 1^st^ trimester US compared to # embryos on 2^nd^ trimester US | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.16 | 0.77 | 1.74
Lambert-Messerlian, Dugoff, Vidaver, et al., 2006 #53400 | Geographical location: Boston, MA; New York, NY; Salt Lake City, Provo, and Ogden, UT; Seattle, WA; Royal Oak, MI; Chapel Hill, NC Study dates: NR, but subset of larger trial with reference given Size of population (no. of patients): IVF with ovulation induction: 277 IUI with ovulation induction: 323 IUI alone: 247 IVF-OI with embryo donation 59 IVF-ED 56 Non-ART: 37,070 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR (adjusted in analysis) Diagnoses (n [%]): NR Inclusion criteria: ART singleton pregnancies Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester serum marker multiple of median, adjusted for gestational age, maternal race, diabetes, weight Screen positive rate calculated at risk of 1:150 for 1^st^ trimester markers, 1:300 for 2^nd^ trimester markers Markers: 1^st^ trimester: Nuchal translucency PAPP-A Free β-hCG 2^nd^ trimester: AFP uE3 hCG Inhibin A | 1) Observed vs expected screen positive rates, 1^st^ trimester markers: | | | | Comments:; - Adjusted for multiple comparisons by using p<0.01 as level of significance; - Other OB outcomes not reported; - No sample size estimate—confidence intervals wide; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Lambert-Messerlian, Dugoff, Vidaver, et al., 2006 #53400 | | Age: NR Race/ethnicity (n [%]): NR (adjusted in analysis) Diagnoses (n [%]): NR Inclusion criteria: ART singleton pregnancies Exclusion criteria: NR
Lambert-Messerlian, Dugoff, Vidaver, et al., 2006 #53400 | | Age: NR Race/ethnicity (n [%]): NR (adjusted in analysis) Diagnoses (n [%]): NR Inclusion criteria: ART singleton pregnancies Exclusion criteria: NR | | Group | Observed (95% CI) | | Expected
Lambert-Messerlian, Dugoff, Vidaver, et al., 2006 #53400 | | Age: NR Race/ethnicity (n [%]): NR (adjusted in analysis) Diagnoses (n [%]): NR Inclusion criteria: ART singleton pregnancies Exclusion criteria: NR | | IVF-OI | 8.6 | 5.3,11.9 | 5.5
Lambert-Messerlian, Dugoff, Vidaver, et al., 2006 #53400 | | Age: NR Race/ethnicity (n [%]): NR (adjusted in analysis) Diagnoses (n [%]): NR Inclusion criteria: ART singleton pregnancies Exclusion criteria: NR | | IUI-OI | 3.4 | 1.4,5.4 | 4.2
Lambert-Messerlian, Dugoff, Vidaver, et al., 2006 #53400 | | Age: NR Race/ethnicity (n [%]): NR (adjusted in analysis) Diagnoses (n [%]): NR Inclusion criteria: ART singleton pregnancies Exclusion criteria: NR | | IUI | 6.1 | 3.1,9.1 | 4.2
Lambert-Messerlian, Dugoff, Vidaver, et al., 2006 #53400 | | Age: NR Race/ethnicity (n [%]): NR (adjusted in analysis) Diagnoses (n [%]): NR Inclusion criteria: ART singleton pregnancies Exclusion criteria: NR | | IVF-OI-ED | 3.4 | 0,8.0 | 2.5
Lambert-Messerlian, Dugoff, Vidaver, et al., 2006 #53400 | | Age: NR Race/ethnicity (n [%]): NR (adjusted in analysis) Diagnoses (n [%]): NR Inclusion criteria: ART singleton pregnancies Exclusion criteria: NR | | IVF-ED | 1.8 | 0,5.3 | 1.0
Lambert-Messerlian, Dugoff, Vidaver, et al., 2006 #53400 | | Age: NR Race/ethnicity (n [%]): NR (adjusted in analysis) Diagnoses (n [%]): NR Inclusion criteria: ART singleton pregnancies Exclusion criteria: NR | | 2) Observed vs expected screen positive rates, 2^nd^ trimester markers:
Lambert-Messerlian, Dugoff, Vidaver, et al., 2006 #53400 | | Age: NR Race/ethnicity (n [%]): NR (adjusted in analysis) Diagnoses (n [%]): NR Inclusion criteria: ART singleton pregnancies Exclusion criteria: NR | | Group | Observed (95% CI) | | Expected
Lambert-Messerlian, Dugoff, Vidaver, et al., 2006 #53400 | | Age: NR Race/ethnicity (n [%]): NR (adjusted in analysis) Diagnoses (n [%]): NR Inclusion criteria: ART singleton pregnancies Exclusion criteria: NR | | IVF-OI | 20.2 | 15.4,25.0 | 14.7*
Lambert-Messerlian, Dugoff, Vidaver, et al., 2006 #53400 | | Age: NR Race/ethnicity (n [%]): NR (adjusted in analysis) Diagnoses (n [%]): NR Inclusion criteria: ART singleton pregnancies Exclusion criteria: NR | | IUI-OI | 21.2 | 16.6,25.7 | 11.9*
Lambert-Messerlian, Dugoff, Vidaver, et al., 2006 #53400 | | Age: NR Race/ethnicity (n [%]): NR (adjusted in analysis) Diagnoses (n [%]): NR Inclusion criteria: ART singleton pregnancies Exclusion criteria: NR | | IUI | 19.1 | 14.1,24.0 | 12.3*
Lambert-Messerlian, Dugoff, Vidaver, et al., 2006 #53400 | | Age: NR Race/ethnicity (n [%]): NR (adjusted in analysis) Diagnoses (n [%]): NR Inclusion criteria: ART singleton pregnancies Exclusion criteria: NR | | IVF-OI-ED | 12.3 | 3.8,20.8 | 7.4
IVF-ED | 7.4 | 0.4,14.4 | 3.9
*p < 0.01
Lerner-Geva, Geva, Lessing, et al., 2003 #17260 | Geographical location: Tel Aviv, Israel Study dates: Treatment for infertility 1984-92; case ascertainment through Israel National Cancer Registry through Dec 1996 Size of population (no. of patients): 1082; Standardized Incidence Ratio calculated for Israeli population Study type: Cohort | Age: Mean (SD): At treatment: 32.7 (4.8) At follow-up: 38.7 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 38 (3.5%) Male factor: 326 (30.1%) Other (specify): Mechanical: 456 (42.1%) Inclusion criteria: Treated with IVF at Tel Aviv Medical Center Exclusion criteria: NR | Definition(s) of outcome(s): Cancer cases by site in Israel National Cancer Registry | 1) Standardized incidence ratios: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: - Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Lerner-Geva, Geva, Lessing, et al., 2003 #17260 | | | Definition(s) of outcome(s): Cancer cases by site in Israel National Cancer Registry
Lerner-Geva, Geva, Lessing, et al., 2003 #17260 | | | Definition(s) of outcome(s): Cancer cases by site in Israel National Cancer Registry | Site | SIR | 95% CI
Lerner-Geva, Geva, Lessing, et al., 2003 #17260 | | | Definition(s) of outcome(s): Cancer cases by site in Israel National Cancer Registry | Breast | 1.02 | 0.33–2.39
Lerner-Geva, Geva, Lessing, et al., 2003 #17260 | | | Definition(s) of outcome(s): Cancer cases by site in Israel National Cancer Registry | Ovary | 5 | 1.02–14.6
Lerner-Geva, Geva, Lessing, et al., 2003 #17260 | | | Definition(s) of outcome(s): Cancer cases by site in Israel National Cancer Registry | Cervix | 4.6 | 0.93–13.5
Lerner-Geva, Geva, Lessing, et al., 2003 #17260 | | | Definition(s) of outcome(s): Cancer cases by site in Israel National Cancer Registry | Other | 2.05 | 0.98–3.78
Other cancers: melanoma (2), Hodgkin's lymphoma (2), multiple myeloma, angiosarcoma, brain, sarcoma, rectum, vulva.
SIRs decreased when cancers diagnosed within 1^st^ year of treatment were excluded.
Lerner-Geva, Keinan-Boker, Blumstein, et al., 2006 #71800 | Geographical location: Israel Study dates: 1964-1984 for treatment, follow-up completed through Dec 1996 Size of population (no. of patients): 5,788 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Seen at one of 5 infertility clinics between 1964-1984 Exclusion criteria: Records unavailable | Definition(s) of outcome(s): Breast cancer in national registry | 1) SIR 1.14 (0.95–1.40) — subjects vs. general population | | | | Comments: Tubal disease more common in frozen group Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results:
Lerner-Geva, Keinan-Boker, Blumstein, et al., 2006 #71800 | Geographical location: Israel Study dates: 1964-1984 for treatment, follow-up completed through Dec 1996 Size of population (no. of patients): 5,788 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Seen at one of 5 infertility clinics between 1964-1984 Exclusion criteria: Records unavailable | Definition(s) of outcome(s): Breast cancer in national registry | 2) Breast cancer incidence, treated infertility vs. untreated infertility:
Lerner-Geva, Keinan-Boker, Blumstein, et al., 2006 #71800 | Geographical location: Israel Study dates: 1964-1984 for treatment, follow-up completed through Dec 1996 Size of population (no. of patients): 5,788 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Seen at one of 5 infertility clinics between 1964-1984 Exclusion criteria: Records unavailable | Definition(s) of outcome(s): Breast cancer in national registry | | Breast cancer + | Breast cancer - | Total
Lerner-Geva, Keinan-Boker, Blumstein, et al., 2006 #71800 | Geographical location: Israel Study dates: 1964-1984 for treatment, follow-up completed through Dec 1996 Size of population (no. of patients): 5,788 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Seen at one of 5 infertility clinics between 1964-1984 Exclusion criteria: Records unavailable | Definition(s) of outcome(s): Breast cancer in national registry | Treated infert | 73 | 3003 | 3076
Lerner-Geva, Keinan-Boker, Blumstein, et al., 2006 #71800 | Geographical location: Israel Study dates: 1964-1984 for treatment, follow-up completed through Dec 1996 Size of population (no. of patients): 5,788 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Seen at one of 5 infertility clinics between 1964-1984 Exclusion criteria: Records unavailable | Definition(s) of outcome(s): Breast cancer in national registry | No treatment | 58 | 2654 | 2712
Lerner-Geva, Keinan-Boker, Blumstein, et al., 2006 #71800 | Geographical location: Israel Study dates: 1964-1984 for treatment, follow-up completed through Dec 1996 Size of population (no. of patients): 5,788 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Seen at one of 5 infertility clinics between 1964-1984 Exclusion criteria: Records unavailable | Definition(s) of outcome(s): Breast cancer in national registry | Total | 131 | 5657 | 5788
Lerner-Geva, Keinan-Boker, Blumstein, et al., 2006 #71800 | Geographical location: Israel Study dates: 1964-1984 for treatment, follow-up completed through Dec 1996 Size of population (no. of patients): 5,788 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Seen at one of 5 infertility clinics between 1964-1984 Exclusion criteria: Records unavailable | Definition(s) of outcome(s): Breast cancer in national registry | | Value | Lower 95% CI | Upper 95% CI
Lerner-Geva, Keinan-Boker, Blumstein, et al., 2006 #71800 | Geographical location: Israel Study dates: 1964-1984 for treatment, follow-up completed through Dec 1996 Size of population (no. of patients): 5,788 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Seen at one of 5 infertility clinics between 1964-1984 Exclusion criteria: Records unavailable | Definition(s) of outcome(s): Breast cancer in national registry | Rel risk | 1.11 | 0.79 | 1.56
3) Risk increased for women treated with clomiphene compared to other infertile women (hazard ratio 1.45, 95 CI 1.10,1.89)
Lidegaard, Pinborg, and Andersen, 2005 #9350 | Geographical location: Copenhagen, Denmark Study dates: Jan 1995 – Dec 2001 Size of population: 442,349 non-IVF, 6,052 IVF Study type: Cohort study | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - All singletons born in Denmark; - IVF pregnancies identified by IVF registry; Exclusion criteria: Twins & other multiples Each child only allowed to be counted once with Dx in each of 5 main Dx grps | Definition(s) of outcome(s): Diagnosis codes for known imprinting diseases used, as well as codes for diseases that might have been used in children with symptoms but no diagnosis of specific disorder Mean f/u time 4.5 yr for non-IVF group, 4.1 yr for IVF | 1) No difference in rates of childhood cancers, mental diseases, congenital syndromes, or developmental disturbances between grps (data not given). | | | | Comments:; - Limitations of using diagnosis codes to define outcome; - Outcome considered is rare - even with large sample size did not have any cases in IVF grp; - CP finding interesting, but no adjustment made for gestational age at delivery; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - not prospective, but unbiased Large sample size: + Adequate description of the cohort: + Use of validated method for genomic test: NA Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: ? Completeness of follow-up: - Analysis (multivariate adjustments) and reporting of results: -
Lidegaard, Pinborg, and Andersen, 2005 #9350 | Geographical location: Copenhagen, Denmark Study dates: Jan 1995 – Dec 2001 Size of population: 442,349 non-IVF, 6,052 IVF Study type: Cohort study | | | 2) Imprinting disorders:
Lidegaard, Pinborg, and Andersen, 2005 #9350 | Geographical location: Copenhagen, Denmark Study dates: Jan 1995 – Dec 2001 Size of population: 442,349 non-IVF, 6,052 IVF Study type: Cohort study | | | | Imprint+ | Imprint- | Total
Lidegaard, Pinborg, and Andersen, 2005 #9350 | Geographical location: Copenhagen, Denmark Study dates: Jan 1995 – Dec 2001 Size of population: 442,349 non-IVF, 6,052 IVF Study type: Cohort study | | | IVF | 0.5 | 6052 | 6052.5
Lidegaard, Pinborg, and Andersen, 2005 #9350 | Geographical location: Copenhagen, Denmark Study dates: Jan 1995 – Dec 2001 Size of population: 442,349 non-IVF, 6,052 IVF Study type: Cohort study | | | non-IVF | 54 | 442295 | 442349
Lidegaard, Pinborg, and Andersen, 2005 #9350 | Geographical location: Copenhagen, Denmark Study dates: Jan 1995 – Dec 2001 Size of population: 442,349 non-IVF, 6,052 IVF Study type: Cohort study | | | Total | 54.5 | 448347 | 448401.5
Lidegaard, Pinborg, and Andersen, 2005 #9350 | Geographical location: Copenhagen, Denmark Study dates: Jan 1995 – Dec 2001 Size of population: 442,349 non-IVF, 6,052 IVF Study type: Cohort study | | | | Value | Lower 95% CI | Upper 95% CI
Lidegaard, Pinborg, and Andersen, 2005 #9350 | Geographical location: Copenhagen, Denmark Study dates: Jan 1995 – Dec 2001 Size of population: 442,349 non-IVF, 6,052 IVF Study type: Cohort study | | | Rel risk | 0.68 | 0.04 | 10.96
Lidegaard, Pinborg, and Andersen, 2005 #9350 | Geographical location: Copenhagen, Denmark Study dates: Jan 1995 – Dec 2001 Size of population: 442,349 non-IVF, 6,052 IVF Study type: Cohort study | | | 3) CP:
Lidegaard, Pinborg, and Andersen, 2005 #9350 | Geographical location: Copenhagen, Denmark Study dates: Jan 1995 – Dec 2001 Size of population: 442,349 non-IVF, 6,052 IVF Study type: Cohort study | | | | CP + | CP - | Total
Lidegaard, Pinborg, and Andersen, 2005 #9350 | Geographical location: Copenhagen, Denmark Study dates: Jan 1995 – Dec 2001 Size of population: 442,349 non-IVF, 6,052 IVF Study type: Cohort study | | | IVF | 20 | 6032 | 6052
Lidegaard, Pinborg, and Andersen, 2005 #9350 | Geographical location: Copenhagen, Denmark Study dates: Jan 1995 – Dec 2001 Size of population: 442,349 non-IVF, 6,052 IVF Study type: Cohort study | | | Non-IVF | 819 | 441530 | 442349
Lidegaard, Pinborg, and Andersen, 2005 #9350 | Geographical location: Copenhagen, Denmark Study dates: Jan 1995 – Dec 2001 Size of population: 442,349 non-IVF, 6,052 IVF Study type: Cohort study | | | Total | 839 | 447562 | 448401
Lidegaard, Pinborg, and Andersen, 2005 #9350 | Geographical location: Copenhagen, Denmark Study dates: Jan 1995 – Dec 2001 Size of population: 442,349 non-IVF, 6,052 IVF Study type: Cohort study | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.78 | 1.15 | 2.78
Ludwig and Katalinic, 2002 #540 | Geographical location: Lubeck and Mainz, Germany Study dates: Aug 1998–Aug 2000 for exposed, 1990-1998 for unexposed Size of population (no. of patients): ICSI:2687 pregnancies (3372 children), 30940 (unexposed) Study type: Cohort | Age: Mean (SD): ICSI 32.9 (3.9); spontaneous: 28.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Ongoing pregnancy 16 weeks after ICSI (exposed); - Published data from birth registry (unexposed); Exclusion criteria:; - Frozen embryo transfer; - IVF in same cycle | Definition(s) of outcome(s): Major malformations: structural defects of body and/or organs, affecting viability and quality of life and requiring medical intervention | 1) Major malformation: | | | | Comments:; - Different birth years (differential ascertainment/classification), significantly older maternal age—no adjustment; - Unblinded ascertainment; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period:+ Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Ludwig and Katalinic, 2002 #540 | | | Definition(s) of outcome(s): Major malformations: structural defects of body and/or organs, affecting viability and quality of life and requiring medical intervention | | Out + | Out - | Total
Ludwig and Katalinic, 2002 #540 | | | Definition(s) of outcome(s): Major malformations: structural defects of body and/or organs, affecting viability and quality of life and requiring medical intervention | ICSI + | 291 | 3081 | 3372
Ludwig and Katalinic, 2002 #540 | | | Definition(s) of outcome(s): Major malformations: structural defects of body and/or organs, affecting viability and quality of life and requiring medical intervention | ICSI - | 2140 | 28800 | 30940
Ludwig and Katalinic, 2002 #540 | | | Definition(s) of outcome(s): Major malformations: structural defects of body and/or organs, affecting viability and quality of life and requiring medical intervention | Total | 2431 | 31881 | 34312
Ludwig and Katalinic, 2002 #540 | | | Definition(s) of outcome(s): Major malformations: structural defects of body and/or organs, affecting viability and quality of life and requiring medical intervention | | Value | Lower 95% CI | Upper 95% CI
Ludwig and Katalinic, 2002 #540 | | | Definition(s) of outcome(s): Major malformations: structural defects of body and/or organs, affecting viability and quality of life and requiring medical intervention | Rel risk | 1.25 | 1.11 | 1.40
No patterns seen for specific organ systems, but overall number small
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | Age: Mean (SD): Assisted 33.1 (4.9) Spontaneous 24.8 (6.1) Race/ethnicity (n [%]): Assisted n=352 White 81% Black 7% Hispanic 7% Spontaneous White 37% Black 36% Hispanic 23% Diagnoses (n [%]): NR Inclusion criteria: Both twins liveborn >=24wks gestation Documented sexes & bwts No major congenital anomalies Maternal height, pregravid weight, and at least 3 prenatal weights with 1^st^ at or before 20wks and the last within 1wk delivery Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | 1) Preeclampsia by assisted vs. spontaneous conception of twins: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - retrospective chart review Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining clinical outcomes: +/- Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | | preeclampsia + | preeclampsia - | Total
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | assisted | 70 | 282 | 352
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | spontaneous | 174 | 551 | 725
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | Total | 244 | 833 | 1077
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | | Value | Lower 95% CI | Upper 95% CI
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | Rel risk | 0.83 | 0.65 | 1.06
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | 2) PPROM:
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | | PPROM + | PPROM- | Total
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | assisted | 70 | 282 | 352
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | spontaneous | 174 | 551 | 725
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | Total | 244 | 833 | 1077
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | | Value | Lower 95% CI | Upper 95% CI
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | Rel risk | 0.83 | 0.65 | 1.06
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | 3) LBWT:
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | | LBWT+ | LBWT- | Total
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | assisted | 204 | 148 | 352
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | spontaneous | 246 | 479 | 725
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | Total | 450 | 627 | 1077
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | | Value | Lower 95% CI | Upper 95% CI
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | Rel risk | 1.71 | 1.49 | 1.95
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | 4) VLBWT:
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | | VLBWT+ | VLBWT- | Total
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | assisted | 39 | 313 | 352
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | spontaneous | 109 | 616 | 725
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | Total | 148 | 929 | 1077
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | | Value | Lower 95% CI | Upper 95% CI
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | Rel risk | 0.74 | 0.52 | 1.04
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | 5) FGR midgestation:
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | | FGR+ | FGR- | Total
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | assisted | 53 | 299 | 352
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | spontaneous | 181 | 544 | 725
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | Total | 234 | 843 | 1077
Luke, Brown, Nugent, et al. 2004 #13930 | Geographical location: Baltimore, MD Miami, FL Ann Arbor, MI Charleston, SC Study dates: 1990 - 2002 Size of population: 1,436 Study type: Cohort, retrospective | | Definition(s) of outcome(s): Preeclampsia- not defined PPROM - not defined LBWT < 2500gm VLBWT < 1500gm FGR < 10% at 20–28wks PTD < 32wks & < 30wks but individual #s not provided | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.60 | 0.46 | 0.80
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | Age: Mean (SD): ART 37(5.4) OI 31(4) Ctrl 28(5.5) Race/ethnicity (n [%]): ART 91% white, 5% Hispanic, 0 black OI 91% white, 5% Hispanic, 1.5% black Controls 69% white, 15% Hispanic, 13% black Diagnoses (n [%]): NR Inclusion criteria: Multiple births from women who delivered in study period at CO KP facilities Exclusion criteria: 2^nd^ set of multiple births (2 mothers) | Definition(s) of outcome(s): Preexisting HTN = 140/90 before conception or < 20wks ART - procedures that involved handling of human oocytes or embryos Preeclampsia = 30/15 increase or 140/90 > 20 wk × 2 occasions ≥6 h apart + 1+ proteinuria or 300mg/24h + edema Severe preeclampsia = 160/110, 5 g prot/24 h or 3+, oliguria < 500 cc/24 h, elevated creat, thrombocytopenia, elevated liver enzymes, cerebral or visual disturbances, epigastric pain, pulmonary edema or cyanosis, FGR, oligohydramnios | 1) Preeclampsia: | | | | Comments: ART/OI older, more often white, married, nulliparous - adjusted for nulliparity Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: n/a Analysis (multivariate adjustments) and reporting of results: +
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | | Preex + | Preex - | Total
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | ART | 27 | 42 | 69
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | Spont | 40 | 290 | 330
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | Total | 67 | 332 | 399
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | | Value | Lower 95% CI | Upper 95% CI
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | Odds rat | 4.66 | 2.59 | 8.37
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | | Preex + | Preex - | Total
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | CC | 18 | 73 | 91
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | spont | 40 | 290 | 330
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | Total | 58 | 363 | 421
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | | Value | Lower 95% CI | Upper 95% CI
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | Odds rat | 1.79 | 0.97 | 3.30
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | | Preex + | Preex - | Total
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | HMG | 9 | 29 | 38
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | spont | 40 | 290 | 330
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | Total | 49 | 319 | 368
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | | Value | Lower 95% CI | Upper 95% CI
Lynch, McDuffie, Murphy, et al., 2002 #2690 | Geographical location: Denver, CO Study dates: Jan 1994–Nov 2000 Size of population: 528 mothers who delivered multiple gestations during study period Study type: Cohort (retrospective) | | | Odds rat | 2.25 | 0.99 | 5.10
Performed 2 multivariate logistic regressions, full and backward. (?) ART was significantly associated with preeclampsia when adjusted for maternal age and nulliparity (AOR 2.8 [1.1, 7]) - CC, HMG were not.
Lynch, McDuffie, Stephens, et al., 2003 #16930 | Geographical location: Boulder, CO Study dates: Jan 1994 – Dec 2001 Size of population: 562 sets of twins Study type: Cohort (retrospective) | Age: Range: 75 (39%) ≥35yo in assisted grp 43 (12%) ≥35yo in unassisted grp Race/ethnicity (n [%]): N(%) refers to women. 432 (77%) White 62 (11%) Hispanic 50 (9%) Af Am 18 (3.3%) other Diagnoses (n [%]): NR Inclusion criteria: Twins delivered > 20wks Exclusion criteria: 2 women gave birth to 2 sets of twins; 2^nd^ set for each excluded | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g | 1) Selective fetal reduction: | | | | Comments: Assisted grp older, less Af Am, more nullip, less single, fewer smokers, higher previous miscarriage rate, fewer monochorionic twins Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for genomic test: Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Lynch, McDuffie, Stephens, et al., 2003 #16930 | Geographical location: Boulder, CO Study dates: Jan 1994 – Dec 2001 Size of population: 562 sets of twins Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g | | Sel red + | Sel red - | Total
Lynch, McDuffie, Stephens, et al., 2003 #16930 | Geographical location: Boulder, CO Study dates: Jan 1994 – Dec 2001 Size of population: 562 sets of twins Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g | Asst | 18 | 175 | 193
Lynch, McDuffie, Stephens, et al., 2003 #16930 | Geographical location: Boulder, CO Study dates: Jan 1994 – Dec 2001 Size of population: 562 sets of twins Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g | Unasst | 0.5 | 369 | 369.5
Lynch, McDuffie, Stephens, et al., 2003 #16930 | Geographical location: Boulder, CO Study dates: Jan 1994 – Dec 2001 Size of population: 562 sets of twins Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g | Total | 18.5 | 544 | 562.5
Lynch, McDuffie, Stephens, et al., 2003 #16930 | Geographical location: Boulder, CO Study dates: Jan 1994 – Dec 2001 Size of population: 562 sets of twins Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g | | Value | Lower 95% CI | Upper 95% CI
Lynch, McDuffie, Stephens, et al., 2003 #16930 | Geographical location: Boulder, CO Study dates: Jan 1994 – Dec 2001 Size of population: 562 sets of twins Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g | Rel risk | 68.92 | 4.17 | 1138.74
Lynch, McDuffie, Stephens, et al., 2003 #16930 | Geographical location: Boulder, CO Study dates: Jan 1994 – Dec 2001 Size of population: 562 sets of twins Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g | 2) LBW:
Lynch, McDuffie, Stephens, et al., 2003 #16930 | Geographical location: Boulder, CO Study dates: Jan 1994 – Dec 2001 Size of population: 562 sets of twins Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g | | LBW + | LBW - | Total
Lynch, McDuffie, Stephens, et al., 2003 #16930 | Geographical location: Boulder, CO Study dates: Jan 1994 – Dec 2001 Size of population: 562 sets of twins Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g | Asst | 113 | 80 | 193
Lynch, McDuffie, Stephens, et al., 2003 #16930 | Geographical location: Boulder, CO Study dates: Jan 1994 – Dec 2001 Size of population: 562 sets of twins Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g | Unasst | 218 | 151 | 369
Lynch, McDuffie, Stephens, et al., 2003 #16930 | Geographical location: Boulder, CO Study dates: Jan 1994 – Dec 2001 Size of population: 562 sets of twins Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g | Total | 331 | 231 | 562
Lynch, McDuffie, Stephens, et al., 2003 #16930 | Geographical location: Boulder, CO Study dates: Jan 1994 – Dec 2001 Size of population: 562 sets of twins Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.99 | 0.86 | 1.15
Maimburg and Vaeth, 2007 #71910 | Geographical location: Denmark (population-based) Study dates: Jan 1990–Dec 1999 Size of population (no. of patients): 473 cases, 473 controls Study type: Case-control | Age: Mean (SD): Maternal: cases 29.1 (4.3) Controls 28.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Cases—all cases entered into national registry; controls—randomly selected from national registry, matched for gender, birth year, birth county Exclusion criteria: NR | Definition(s) of outcome(s): Infantile autism, based on ICD codes, from national registry | 1) Crude odds ratio, infertility treatment vs. spontaneous: | | | | Comments: None Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Comparability of cases and controls with respect to potential confounders: + Appropriateness of statistical analyses: +
Maimburg and Vaeth, 2007 #71910 | Geographical location: Denmark (population-based) Study dates: Jan 1990–Dec 1999 Size of population (no. of patients): 473 cases, 473 controls Study type: Case-control | | Definition(s) of outcome(s): Infantile autism, based on ICD codes, from national registry | | Autism + | Autism - | Total
Maimburg and Vaeth, 2007 #71910 | Geographical location: Denmark (population-based) Study dates: Jan 1990–Dec 1999 Size of population (no. of patients): 473 cases, 473 controls Study type: Case-control | | Definition(s) of outcome(s): Infantile autism, based on ICD codes, from national registry | Infertilty | 10 | 23 | 33
Maimburg and Vaeth, 2007 #71910 | Geographical location: Denmark (population-based) Study dates: Jan 1990–Dec 1999 Size of population (no. of patients): 473 cases, 473 controls Study type: Case-control | | Definition(s) of outcome(s): Infantile autism, based on ICD codes, from national registry | Spont | 463 | 450 | 913
Maimburg and Vaeth, 2007 #71910 | Geographical location: Denmark (population-based) Study dates: Jan 1990–Dec 1999 Size of population (no. of patients): 473 cases, 473 controls Study type: Case-control | | Definition(s) of outcome(s): Infantile autism, based on ICD codes, from national registry | Total | 473 | 473 | 946
Maimburg and Vaeth, 2007 #71910 | Geographical location: Denmark (population-based) Study dates: Jan 1990–Dec 1999 Size of population (no. of patients): 473 cases, 473 controls Study type: Case-control | | Definition(s) of outcome(s): Infantile autism, based on ICD codes, from national registry | | Value | Lower 95% CI | Upper 95% CI
Maimburg and Vaeth, 2007 #71910 | Geographical location: Denmark (population-based) Study dates: Jan 1990–Dec 1999 Size of population (no. of patients): 473 cases, 473 controls Study type: Case-control | | Definition(s) of outcome(s): Infantile autism, based on ICD codes, from national registry | Odds rat | 0.42 | 0.20 | 0.90
Adjusted odds ratio (adjusted for mothers age, mothers' country of origin, parity, multiplicity, birth weight, gestational age and birth defect) 0.37 (0.14–0.98).
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | Age: Mean (SD): IVF 32.3 (6.3) Spontaneous 27.9 (4.8) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin pregnancies Exclusion criteria: Higher order multiples, ovulation induction, reduction to singleton, 1^st^ trimester loss of 1 twin, uncontrolled DM, SLE | Definition(s) of outcome(s): Preeclampsia ≥ 140/90 after 20wks and ≥ 300mg proteinuria/24hr or abnl hematological or biochem markers associated with symptomatology GDM +3hr GTT PPROM PTB < 37wks SGA < 10%ile LBWT < 2500gm Perinatal deaths = stillbirths ≥ 500gm through 7d of life Neonatal death = within 28d of life | 1) Preeclampsia: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): +/- Large sample size: + Adequate description of the cohort: +: Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | preeclampsia+ | preeclampsia- | Total
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | IVF | 3 | 70 | 73
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | spontaneous | 3 | 145 | 148
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Total | 6 | 215 | 221
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | Value | Lower 95% CI | Upper 95% CI
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Rel risk | 2.03 | 0.42 | 9.80
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | 2) GDM:
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | GDM+ | GDM- | Total
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | IVF | 3 | 70 | 73
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | spontaneous | 3 | 145 | 148
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Total | 6 | 215 | 221
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | Value | Lower 95% CI | Upper 95% CI
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Rel risk | 2.03 | 0.42 | 9.80
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | 3) PPROM:
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | PPROM+ | PPROM- | Total
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | IVF | 10 | 63 | 73
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | spontaneous | 8 | 140 | 148
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Total | 18 | 203 | 221
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | Value | Lower 95% CI | Upper 95% CI
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Rel risk | 2.53 | 1.04 | 6.15
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | 4) IUFD:
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | IUFD+ | IUFD- | Total
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | IVF | 7 | 66 | 73
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | spontaneous | 8 | 140 | 148
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Total | 15 | 206 | 221
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | Value | Lower 95% CI | Upper 95% CI
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Rel risk | 1.77 | 0.67 | 4.70
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | 5) C-section:
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | C/S+ | C/S- | Total
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | IVF | 67 | 7 | 74
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | spontaneous | 102 | 46 | 148
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Total | 169 | 53 | 222
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | Value | Lower 95% CI | Upper 95% CI
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Rel risk | 1.31 | 1.15 | 1.50
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | 6) PTB:
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | PTB+ | PTB- | Total
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | IVF | 55 | 18 | 73
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | spontaneous | 91 | 57 | 148
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Total | 146 | 75 | 221
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | Value | Lower 95% CI | Upper 95% CI
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Rel risk | 1.23 | 1.02 | 1.47
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | 7) LBWT:
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | LBWT+ | LBWT- | Total
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | IVF | 90 | 49 | 139
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | spontaneous | 170 | 118 | 288
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Total | 260 | 167 | 427
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | Value | Lower 95% CI | Upper 95% CI
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Rel risk | 1.10 | 0.94 | 1.28
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | 8) SGA:
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | SGA+ | SGA- | Total
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | IVF | 35 | 104 | 139
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | spontaneous | 67 | 221 | 288
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Total | 102 | 325 | 427
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | Value | Lower 95% CI | Upper 95% CI
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Rel risk | 1.08 | 0.76 | 1.54
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | 9) Perinatal death:
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | perinatal death+ | perinatal death- | Total
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | IVF | 11 | 128 | 139
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | spontaneous | 24 | 264 | 288
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Total | 35 | 392 | 427
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | Value | Lower 95% CI | Upper 95% CI
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Rel risk | 0.95 | 0.48 | 1.88
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | 10) Neonatal death:
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | neonatal death+ | neonatal death- | Total
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | IVF | 10 | 129 | 139
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | spontaneous | 18 | 270 | 288
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | Total | 28 | 399 | 427
Manoura, Korakaki, Hatzidaki, et al. 2004 #12220 | Geographical location: Crete, Greece Study dates: July 1994 – July 2002 Size of population: 221 twin pregnancies (427 infants) 73 by IVF & 148 spontaneous Study type: Cohort, retrospective | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.15 | 0.55 | 2.43
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | Data presented are for ALL pregnancies - data presented for singletons and twins in paper | | | | Comments: No adjustment for multiple comparisons, no multivariate adjustment Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): Large sample size: Adequate description of the cohort: Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | 1) SAb by IVF v ICSI:
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | | SAb + | Sab -
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | ICSI | 112 | 560 | 672
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | IVF | 18 | 171 | 189
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | | 130 | 731 | 861
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | | | Lower 95% CI | Upper 95 % CI
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | Rel risk | 1.75 | 1.09 | 2.80
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | 2) SAb by age cutpoint 38 yrs:
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | | Preg + | Preg -
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | > 38 | 26 | 65 | 91
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | ≤ 38 | 104 | 666 | 770
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | | 130 | 731 | 861
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | | | Lower 95% CI | Upper 95 % CI
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | Rel risk | 2.12 | 1.46 | 3.06
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | 3) SAb by embryo transfer day:
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | | Sab+ | Sab- | Total
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | ET2–3 | 78 | 350 | 428
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | ET4–5 | 34 | 190 | 224
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | Total | 112 | 540 | 652
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | | Value | Lower 95% CI | Upper 95% CI
Matias, Oliveira, da Sliva, et al., 2007 #54010 | Geographical location: Porto, Portugal Study dates: 1994-2004 Size of population (no. of patients): 861 = 189 IVF, 672 ICSI Study type: Cohort | Age: < 38 yrs n = 770, 89.4% Race/ethnicity (n [%]): > 95% Portuguese Diagnoses (n [%]): NR Inclusion criteria: IVF ± ICSI Exclusion criteria: NR | Definition(s) of outcome(s): Spontaneous abortion = complete pregnancy loss | Rel risk | 1.20 | 0.83 | 1.74
4) Loss rate higher for singletons than for twin pregnancies, especially in ICSI pregnancies
Maymon, Jauniaux, Holmes, et al., 2001 #4260 | Geographical location: Zrifin, Israel & London, UK Study dates: June 1998 – Nov 1999 Size of population: Art 83 women Spontaneous 91 women Study type: Cohort | Age: ART 31 (4) Spontaneous 32 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins Exclusion criteria: NR | Definition(s) of outcome(s): NR | 1) Abnl NT screen for ART vs spontaneous: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Maymon, Jauniaux, Holmes, et al., 2001 #4260 | Geographical location: Zrifin, Israel & London, UK Study dates: June 1998 – Nov 1999 Size of population: Art 83 women Spontaneous 91 women Study type: Cohort | Age: ART 31 (4) Spontaneous 32 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins Exclusion criteria: NR | Definition(s) of outcome(s): NR | | abnl NT | nl NT | Total
Maymon, Jauniaux, Holmes, et al., 2001 #4260 | Geographical location: Zrifin, Israel & London, UK Study dates: June 1998 – Nov 1999 Size of population: Art 83 women Spontaneous 91 women Study type: Cohort | Age: ART 31 (4) Spontaneous 32 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins Exclusion criteria: NR | Definition(s) of outcome(s): NR | ART | 3 | 80 | 83
Maymon, Jauniaux, Holmes, et al., 2001 #4260 | Geographical location: Zrifin, Israel & London, UK Study dates: June 1998 – Nov 1999 Size of population: Art 83 women Spontaneous 91 women Study type: Cohort | Age: ART 31 (4) Spontaneous 32 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins Exclusion criteria: NR | Definition(s) of outcome(s): NR | spontaneous | 13 | 78 | 91
Maymon, Jauniaux, Holmes, et al., 2001 #4260 | Geographical location: Zrifin, Israel & London, UK Study dates: June 1998 – Nov 1999 Size of population: Art 83 women Spontaneous 91 women Study type: Cohort | Age: ART 31 (4) Spontaneous 32 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins Exclusion criteria: NR | Definition(s) of outcome(s): NR | Total | 16 | 158 | 174
Maymon, Jauniaux, Holmes, et al., 2001 #4260 | Geographical location: Zrifin, Israel & London, UK Study dates: June 1998 – Nov 1999 Size of population: Art 83 women Spontaneous 91 women Study type: Cohort | Age: ART 31 (4) Spontaneous 32 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins Exclusion criteria: NR | Definition(s) of outcome(s): NR | | Value | Lower 95% CI | Upper 95% CI
Maymon, Jauniaux, Holmes, et al., 2001 #4260 | Geographical location: Zrifin, Israel & London, UK Study dates: June 1998 – Nov 1999 Size of population: Art 83 women Spontaneous 91 women Study type: Cohort | Age: ART 31 (4) Spontaneous 32 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins Exclusion criteria: NR | Definition(s) of outcome(s): NR | Rel risk | 0.25 | 0.07 | 0.86
Maymon, Jauniaux, Holmes, et al., 2001 #4260 | Geographical location: Zrifin, Israel & London, UK Study dates: June 1998 – Nov 1999 Size of population: Art 83 women Spontaneous 91 women Study type: Cohort | Age: ART 31 (4) Spontaneous 32 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins Exclusion criteria: NR | Definition(s) of outcome(s): NR | 2) Complicated pregnancy outcome by ART vs spontaneous:
Maymon, Jauniaux, Holmes, et al., 2001 #4260 | Geographical location: Zrifin, Israel & London, UK Study dates: June 1998 – Nov 1999 Size of population: Art 83 women Spontaneous 91 women Study type: Cohort | Age: ART 31 (4) Spontaneous 32 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins Exclusion criteria: NR | Definition(s) of outcome(s): NR | | complicated | not complicated | Total
Maymon, Jauniaux, Holmes, et al., 2001 #4260 | Geographical location: Zrifin, Israel & London, UK Study dates: June 1998 – Nov 1999 Size of population: Art 83 women Spontaneous 91 women Study type: Cohort | Age: ART 31 (4) Spontaneous 32 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins Exclusion criteria: NR | Definition(s) of outcome(s): NR | ART | 4 | 79 | 83
Maymon, Jauniaux, Holmes, et al., 2001 #4260 | Geographical location: Zrifin, Israel & London, UK Study dates: June 1998 – Nov 1999 Size of population: Art 83 women Spontaneous 91 women Study type: Cohort | Age: ART 31 (4) Spontaneous 32 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins Exclusion criteria: NR | Definition(s) of outcome(s): NR | spontaneous | 10 | 81 | 91
Maymon, Jauniaux, Holmes, et al., 2001 #4260 | Geographical location: Zrifin, Israel & London, UK Study dates: June 1998 – Nov 1999 Size of population: Art 83 women Spontaneous 91 women Study type: Cohort | Age: ART 31 (4) Spontaneous 32 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins Exclusion criteria: NR | Definition(s) of outcome(s): NR | Total | 14 | 160 | 174
Maymon, Jauniaux, Holmes, et al., 2001 #4260 | Geographical location: Zrifin, Israel & London, UK Study dates: June 1998 – Nov 1999 Size of population: Art 83 women Spontaneous 91 women Study type: Cohort | Age: ART 31 (4) Spontaneous 32 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins Exclusion criteria: NR | Definition(s) of outcome(s): NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.44 | 0.14 | 1.35
Maymon and Shulman, 2004 #13890 | Geographical location: Tel Aviv, Israel Study dates: Jan 2000–Sept 2002 Size of population (no. of patients): 99 IVF 1781 spontaneous conceptions (lab reference values) Study type: Cohort | Age: Mean (SD): IVF: 32.2 (4) Spontaneous: 30.4 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Selection criteria unclear; - Singleton pregnancies; Exclusion criteria: NR - referenced | Definition(s) of outcome(s): False positive results, based on 1^st^ trimester PAPP-A and nuchal translucency, 2^nd^ trimrester AFP, uE3, hCG, and inhibin A | 1) Relative risk of false positive: | | | | Comments: No adjustment for multiple comparisons Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: - Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Maymon and Shulman, 2004 #13890 | Geographical location: Tel Aviv, Israel Study dates: Jan 2000–Sept 2002 Size of population (no. of patients): 99 IVF 1781 spontaneous conceptions (lab reference values) Study type: Cohort | | Definition(s) of outcome(s): False positive results, based on 1^st^ trimester PAPP-A and nuchal translucency, 2^nd^ trimrester AFP, uE3, hCG, and inhibin A | | False + | | Total
Maymon and Shulman, 2004 #13890 | Geographical location: Tel Aviv, Israel Study dates: Jan 2000–Sept 2002 Size of population (no. of patients): 99 IVF 1781 spontaneous conceptions (lab reference values) Study type: Cohort | | Definition(s) of outcome(s): False positive results, based on 1^st^ trimester PAPP-A and nuchal translucency, 2^nd^ trimrester AFP, uE3, hCG, and inhibin A | IVF + | 6 | 93 | 99
Maymon and Shulman, 2004 #13890 | Geographical location: Tel Aviv, Israel Study dates: Jan 2000–Sept 2002 Size of population (no. of patients): 99 IVF 1781 spontaneous conceptions (lab reference values) Study type: Cohort | | Definition(s) of outcome(s): False positive results, based on 1^st^ trimester PAPP-A and nuchal translucency, 2^nd^ trimrester AFP, uE3, hCG, and inhibin A | Spont | 66 | 1715 | 1781
Maymon and Shulman, 2004 #13890 | Geographical location: Tel Aviv, Israel Study dates: Jan 2000–Sept 2002 Size of population (no. of patients): 99 IVF 1781 spontaneous conceptions (lab reference values) Study type: Cohort | | Definition(s) of outcome(s): False positive results, based on 1^st^ trimester PAPP-A and nuchal translucency, 2^nd^ trimrester AFP, uE3, hCG, and inhibin A | Total | 72 | 1808 | 1880
Maymon and Shulman, 2004 #13890 | Geographical location: Tel Aviv, Israel Study dates: Jan 2000–Sept 2002 Size of population (no. of patients): 99 IVF 1781 spontaneous conceptions (lab reference values) Study type: Cohort | | Definition(s) of outcome(s): False positive results, based on 1^st^ trimester PAPP-A and nuchal translucency, 2^nd^ trimrester AFP, uE3, hCG, and inhibin A | | Value | Lower 95% CI | Upper 95% CI
Maymon and Shulman, 2004 #13890 | Geographical location: Tel Aviv, Israel Study dates: Jan 2000–Sept 2002 Size of population (no. of patients): 99 IVF 1781 spontaneous conceptions (lab reference values) Study type: Cohort | | Definition(s) of outcome(s): False positive results, based on 1^st^ trimester PAPP-A and nuchal translucency, 2^nd^ trimrester AFP, uE3, hCG, and inhibin A | Rel risk | 1.64 | 0.73 | 3.68
2) Nuchal translucency MOM significantly higher, PAPP-A significantly lower in IVF pregnancies. 2^nd^ trimester markers not significantly different.
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | Age: IVF 31.5 (5) Spontaneous 30 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singleton 10 – 14 wks Exclusion criteria: >1 fetus, chromosomal aneuploidy, <24wks pregnancy loss, congenital anomalies | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | 1) 1^st^ trimester false-positive for IVF vs spontaneous: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) - and reporting of results: -
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | | screen+ | screen- | Total
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | IVF | 5 | 66 | 71
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | spontaneous | 26 | 259 | 285
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | Total | 31 | 325 | 356
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | | Value | Lower 95% CI | Upper 95% CI
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | Rel risk | 0.77 | 0.31 | 1.94
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | 2) 2^nd^ trimester false-positive for IVF vs spontaneous:
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | | screen+ | screen- | Total
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | IVF | 7 | 64 | 71
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | spontaneous | 14 | 271 | 285
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | Total | 21 | 335 | 356
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | | Value | Lower 95% CI | Upper 95% CI
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | Rel risk | 2.01 | 0.84 | 4.79
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | 3) 1^st^ & 2^nd^ trimester false positive for IVF vs spontaneous:
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | | screen+ | screen- | Total
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | IVF | 1 | 70 | 71
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | spontaneous | 4 | 281 | 285
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | Total | 5 | 351 | 356
Maymon and Shulman, 2002 #2400 | Geographical location: Tel Aviv, Israel Study dates: Jan 1999 – Sept 2000 Size of population: IVF 71 Spontaneous 285 Study type: Cohort | | Definition(s) of outcome(s): False positive rate for 1^st^ and 2^nd^ trimester screening tests | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.00 | 0.11 | 8.84
McMahon and Gibson, 2002 #530 | Geographical location: Sydney, Australia Study dates: NR Size of population (no. of patients): 70 IVF couples, 63 controls Number of cycles per patient: Mean 5.0 (3.8), range 1–23 Study type: Cohort | Age: Mean (SD): IVF 34.5 (3.0) Control 31.9 (2.4) Paternal age also higher in IVF group Race/ethnicity (n [%]): NR College education: 40% IVF, 53% controls Diagnoses (n [%]): NR Inclusion criteria: IVF:; - No donor; - First singleton pregnancy; - Mother living with father Controls:; - First singleton pregnancy; - Mother living with father; Exclusion criteria: NR | Definition(s) of outcome(s): Pregnancy 30 weeks: questionnaire/interviews; instruments not explicitly described/references Mother-infant relationship at 4 months: Still-Face Procedure (standardized, videotaped, maternal and infant behaviors coded by blinded scorers) 12 months: Strange Situation (standardized, videotaped, maternal and infant behaviors coded by blinded scorers) Both instruments involve separation of infant from mother, observation of behaviors after reunion | 1) 30 weeks: IVF mothers: lower self-esteem, greater external locus of control; much higher anxiety about defects in baby, injury during birth; fathers: lower self-esteem, higher trait anxiety, lower marital satisfaction 2) 4 months: IVF infants with more fussing, but no significant difference in maternal behaviors (despite self-reported lower feelings of competence among IVF mothers) 3) 12 months: Questionnaires: no differences in mothers, infants; IVF fathers report lower self-esteem, less caring from spouses Mothers reported more difficult infants, but no differences in observed behaviors. | | | | Comments:; - Methodology for selecting subjects not described.; - Instruments for 30 week questionnaires not described, but, given terminology, likely to be standard instruments such as State-Trait Anxiety Index (referenced in earlier paper); - Large (2–9 fold) differences in preterm, low birthweight, NICU admission—not adjusted in analyses; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - (NR) Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Meijer, de Jong-Van den Berg, Van den Berg, et al., 2006 #54100 | Geographical location: The Netherlands Study dates: 1981-2003 Size of population (no. of patients): 392 cases, Study type: Case-control | Age: Mean (SD): Median: Range: Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Cases—male infants with hypospadias Controls—male infants with malformations other than hypospadias Exclusion criteria:; - Hypospadias as part of a syndrome; - Epispadia | Definition(s) of outcome(s): | 1) Crude odds ratio, all hypospadias, exposure=clomiphene: | | | | Comments:; - Small numbers don't allow multivariate analysis; - No adjustment for multiple comparisons; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: - Comparability of cases and controls with respect to potential confounders: - Appropriateness of statistical analyses: +
Meijer, de Jong-Van den Berg, Van den Berg, et al., 2006 #54100 | Geographical location: The Netherlands Study dates: 1981-2003 Size of population (no. of patients): 392 cases, Study type: Case-control | | Definition(s) of outcome(s): | | Out + | Out - | Total
Meijer, de Jong-Van den Berg, Van den Berg, et al., 2006 #54100 | Geographical location: The Netherlands Study dates: 1981-2003 Size of population (no. of patients): 392 cases, Study type: Case-control | | Definition(s) of outcome(s): | Clompihene + | 7 | 64 | 71
Meijer, de Jong-Van den Berg, Van den Berg, et al., 2006 #54100 | Geographical location: The Netherlands Study dates: 1981-2003 Size of population (no. of patients): 392 cases, Study type: Case-control | | Definition(s) of outcome(s): | Clomiphene - | 385 | 4474 | 4859
Meijer, de Jong-Van den Berg, Van den Berg, et al., 2006 #54100 | Geographical location: The Netherlands Study dates: 1981-2003 Size of population (no. of patients): 392 cases, Study type: Case-control | | Definition(s) of outcome(s): | Total | 392 | 4538 | 4930
Meijer, de Jong-Van den Berg, Van den Berg, et al., 2006 #54100 | Geographical location: The Netherlands Study dates: 1981-2003 Size of population (no. of patients): 392 cases, Study type: Case-control | | Definition(s) of outcome(s): | | Value | Lower 95% CI | Upper 95% CI
Meijer, de Jong-Van den Berg, Van den Berg, et al., 2006 #54100 | Geographical location: The Netherlands Study dates: 1981-2003 Size of population (no. of patients): 392 cases, Study type: Case-control | | Definition(s) of outcome(s): | Odds ratio | 1.27 | 0.58 | 2.79
2) Odds ratio for penoscrotal hypospadias 6.08 (1.4, 26.3), but based on only 25 cases
Merlob, Sapir, Sulkes, et al., 2005 #8910 | Geographical location: Petah Tiqva, Israel Study dates: 1986 - 1994, and 1995 - 2002 Size of population: 1986 - 1994: 31,007 infants (278 IVF) 1995 - 2002: 53,208 infants (1,632 ART) Study type: Cohort study | Age: NR (infants) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - All infants (livebirths, stillbirths, terminations) delivered at one center > 20 wk and weighing ≥ 500 g; - 1986 - 94, “standard IVF”; - 1995 - 2002, ART compared with spontaneously conceived infants delivered in same time periods; Exclusion criteria: < 20wks, < 500g | Definition(s) of outcome(s): Major malformations (structural and chromosomal) diagnosed pre- or postnatally Excluded minor malformations (listed) | 1) Major malformations by IVF, 1986 - 1994: | | | | Comments:; - Included stillbirths & terminations - important in eliminating bias; - ART grp significantly older than spontaneous conception grp and contained significant percentage of multiple births (known risk factors, not controlled for); - Dx included prenatal diagnosis + physical exam of newborn; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - not prospective, but minimally biased Large sample size: + Adequate description of the cohort: + (but would have liked to know what % liveborn, stillborn, terminated) Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Merlob, Sapir, Sulkes, et al., 2005 #8910 | | | Definition(s) of outcome(s): Major malformations (structural and chromosomal) diagnosed pre- or postnatally Excluded minor malformations (listed) | | Major malform+ | Major malform - | Total
Merlob, Sapir, Sulkes, et al., 2005 #8910 | | | Definition(s) of outcome(s): Major malformations (structural and chromosomal) diagnosed pre- or postnatally Excluded minor malformations (listed) | IVF + | 26 | 252 | 278
Merlob, Sapir, Sulkes, et al., 2005 #8910 | | | Definition(s) of outcome(s): Major malformations (structural and chromosomal) diagnosed pre- or postnatally Excluded minor malformations (listed) | IVF - | 1248 | 29481 | 30729
Merlob, Sapir, Sulkes, et al., 2005 #8910 | | | Definition(s) of outcome(s): Major malformations (structural and chromosomal) diagnosed pre- or postnatally Excluded minor malformations (listed) | Total | 1274 | 29733 | 31007
Merlob, Sapir, Sulkes, et al., 2005 #8910 | | | Definition(s) of outcome(s): Major malformations (structural and chromosomal) diagnosed pre- or postnatally Excluded minor malformations (listed) | | Value | Lower 95% CI | Upper 95% CI
Merlob, Sapir, Sulkes, et al., 2005 #8910 | | | Definition(s) of outcome(s): Major malformations (structural and chromosomal) diagnosed pre- or postnatally Excluded minor malformations (listed) | Rel risk | 2.30 | 1.59 | 3.33
Merlob, Sapir, Sulkes, et al., 2005 #8910 | | | Definition(s) of outcome(s): Major malformations (structural and chromosomal) diagnosed pre- or postnatally Excluded minor malformations (listed) | 2) Major malformation by ART, 1995 - 2002:
Merlob, Sapir, Sulkes, et al., 2005 #8910 | | | Definition(s) of outcome(s): Major malformations (structural and chromosomal) diagnosed pre- or postnatally Excluded minor malformations (listed) | | Major malform+ | Major malform - | Total
Merlob, Sapir, Sulkes, et al., 2005 #8910 | | | Definition(s) of outcome(s): Major malformations (structural and chromosomal) diagnosed pre- or postnatally Excluded minor malformations (listed) | ART + | 147 | 1485 | 1632
Merlob, Sapir, Sulkes, et al., 2005 #8910 | | | Definition(s) of outcome(s): Major malformations (structural and chromosomal) diagnosed pre- or postnatally Excluded minor malformations (listed) | ART - | 2681 | 48895 | 51576
Merlob, Sapir, Sulkes, et al., 2005 #8910 | | | Definition(s) of outcome(s): Major malformations (structural and chromosomal) diagnosed pre- or postnatally Excluded minor malformations (listed) | Total | 2828 | 50380 | 53208
Merlob, Sapir, Sulkes, et al., 2005 #8910 | | | Definition(s) of outcome(s): Major malformations (structural and chromosomal) diagnosed pre- or postnatally Excluded minor malformations (listed) | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.73 | 1.48 | 2.03
Muller, Dreux, Lemeur, et al., 2003 #14500 | Geographical location: Paris, Lyon, Dijon, Lyon, Marseille, Amiens, and Nantes, France Study dates: 1996-2002 Size of population (no. of patients): 1515 ART pregnancies 21,014 spontaneous conceptions Study type: Cohort | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | 1) Relative risk for positive result (calculated risk > 1/250), all pregnancies: | | | | Comments:; - All subjects had AFP; additional markers varied—not adjusted for variation in tests used; - OB outcomes not reported; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining exposure: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | | Out + | Out - | Total
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | ART + | 192 | 1323 | 1515
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Spont | 1849 | 19165 | 21014
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Total | 2041 | 20488 | 22529
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | | Value | Lower 95% CI | Upper 95% CI
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Rel risk | 1.44 | 1.25 | 1.66
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | 2) Relative risk for positive result (calculated risk > 1/250), women < 30 years old:
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | | Out + | Out - | Total
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | ART + | 11 | 330 | 341
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Spont | 298 | 9621 | 9919
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Total | 309 | 9951 | 10260
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | | Value | Lower 95% CI | Upper 95% CI
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Rel risk | 1.07 | 0.59 | 1.94
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | 3) Relative risk for positive result (calculated risk > 1/250), women 30–34 years old:
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | | Out + | Out - | Total
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Exp + | 63 | 631 | 694
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Exp - | 569 | 6638 | 7207
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Total | 632 | 7269 | 7901
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | | Value | Lower 95% CI | Upper 95% CI
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Rel risk | 1.15 | 0.90 | 1.47
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | 4) Relative risk for positive result (calculated risk > 1/250), women 35–37 years old:
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | | Out + | Out - | Total
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Exp + | 63 | 273 | 336
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Exp - | 461 | 2145 | 2606
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Total | 524 | 2418 | 2942
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | | Value | Lower 95% CI | Upper 95% CI
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Rel risk | 1.06 | 0.84 | 1.34
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | 5) Relative risk for positive result (calculated risk > 1/250), women ≥ 38 years old:
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | | Out + | Out - | Total
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Exp + | 57 | 87 | 144
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Exp - | 515 | 767 | 1282
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | Total | 572 | 854 | 1426
Muller, Dreux, Lemeur, et al., 2003 #14500 | | Age: ART: 31.7% ≥ 35 Spontaneous: 18.5% ≥35 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: Embryo reduction | Definition(s) of outcome(s): 2^nd^ trimester screening using AFP (all pregnancies), hCG, free β-hCG, and uE3 | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.99 | 0.80 | 1.22
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | Age: Ov induction 29 yrs Spontaneous 27.8 yrs Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins >=28 wks with subfertility treated by ovulation induction-only, controls spontaneous conception Exclusion criteria: Any ART more advanced than ovulation induction | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | 1) Preterm birth: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | | ptb+ | ptb- | Total
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | ov indx | 146 | 248 | 394
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | spontaneous | 1243 | 2280 | 3523
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | Total | 1389 | 2528 | 3917
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | | Value | Lower 95% CI | Upper 95% CI
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | Rel risk | 1.05 | 0.92 | 1.20
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | 2) Low birthweight:
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | | lbwt+ | lbwt- | Total
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | ov indx | 189 | 205 | 394
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | spontaneous | 1650 | 1873 | 3523
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | Total | 1839 | 2078 | 3917
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | | Value | Lower 95% CI | Upper 95% CI
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | Rel risk | 1.02 | 0.92 | 1.14
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | 3) Perinatal mortality:
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | | perinatal mort+ | perinatal mort- | Total
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | ov indx | 11 | 383 | 394
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | spontaneous | 98 | 3425 | 3523
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | Total | 109 | 3808 | 3917
Murphy, Neale, Hey, et al., 2006 #54340 | Geographical location: United Kingdom Study dates: 1973 - 1989 Size of population (no. of patients): All twins N=199 ovulation induction N=1773 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Perinatal mortality = stillbirth + neonatal death | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.00 | 0.54 | 1.86
Nassar, Usta, Rechdam, et al., 2003 #15350 | Geographical location: Beirut, Lebanon Study dates: Jan 1995 – Dec 2000 Size of population: 56 IVF twin pregnancies 112 spont twin preg Study type: IVF twins matched by age & parity 1:2 to spontaneous twins, sequentially at time of delivery. | Age: Mean (SD): 31 (5) Race/ethnicity (n [%]): Middle eastern (all) Diagnoses (n [%]): NR Inclusion criteria: Twin pregnancies delivered >= 25 wks Exclusion criteria: Women who underwent ovulation induction only, multifetal pregnancy reduction, or with medical disease (CHtn, DM, renal disease) | Definition(s) of outcome(s): Hypertensive disorders of pregnancy = BP > 140/90 on ≥ 2 occasions > 20wks in previously normotensive woman PTD < 37wks, extremely premature ≤ 32wks IUGR = birthwt <10^th^ %ile for singletons | 1) Preterm delivery < 37wks: | | | | Comments:; - Excluded those who delivered <25wks; - Racially homogeneous sample; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: + Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | | PTD + | PTD - | Total
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | IVF | 38 | 18 | 56
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | spont | 46 | 66 | 112
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | Total | 84 | 84 | 168
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | | Value | Lower 95% CI | Upper 95% CI
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | Odds rat | 3.03 | 1.54 | 5.95
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | 2) C/S (despite similar rates of elective C/S and malpresenting Twin A):
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | | CS + | CS - | Total
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | IVF | 43 | 13 | 56
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | spont | 65 | 47 | 112
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | Total | 108 | 60 | 168
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | | Value | Lower 95% CI | Upper 95% CI
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | Odds rat | 2.39 | 1.16 | 4.94
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | 3) RDS:
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | | RDS + | RDS - | Total
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | IVF | 14 | 42 | 56
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | spont | 9 | 103 | 112
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | Total | 23 | 145 | 168
Nassar, Usta, Rechdam, et al., 2003 #15350 | | | | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 3.81 | 1.53 | 9.49
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | Geographical location: Munich, Germany Study dates: 1991-96 Size of population: 322 singleton, 78 twins conceived by IVF or GIFT Study type: Cohort IVF/GIFT conceptions identified retrospectively from database, then matched; next respective spontaneously-conceived singleton or twin pregnancy in database matched for maternal age, gestational age, and parity | Age: Mean: GIFT/IVF: 32.6 Controls: 32.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singleton and twin pregnancies conceived by GIFT or IVF with liveborns ≥ 24 wk and/or > 499 g Exclusion criteria: NR | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | 1) C/S in singletons: | | | | Comments: Matching performed retrospectively based in part on GA at delivery; thus not possible to compare GA or prematurity-related complications Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: - Appropriateness of the control population: + Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: - Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | | C/S + | C/S - | Total
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | IVF/GIFT | 86 | 276 | 362
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | Spont | 73 | 249 | 322
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | Total | 159 | 525 | 684
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | | Value | Lower 95% CI | Upper 95% CI
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | Odds rat | 1.06 | 0.74 | 1.52
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | 2) Vaginal bleeding in singletons:
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | | VB + | VB - | Total
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | IVF/GIFT | 13 | 349 | 362
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | Spont | 3 | 319 | 322
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | Total | 16 | 668 | 684
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | | Value | Lower 95% CI | Upper 95% CI
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | Odds rat | 3.96 | 1.12 | 14.03
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | 3) Pregnancy-induced HTN in singletons:
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | | PIH+ | PIH - | Total
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | IVF/GIFT | 12 | 350 | 362
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | Spont | 3 | 319 | 322
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | Total | 15 | 669 | 684
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | | Value | Lower 95% CI | Upper 95% CI
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | Odds rat | 3.65 | 1.02 | 13.04
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | 4) C/S in twins:
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | | C/S + | C/S - | Total
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | IVF/GIFT | 54 | 24 | 78
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | Spont | 43 | 35 | 78
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | Total | 97 | 59 | 156
Ochsenkuhn, Strowitzki, Gurtner, et al., 2003 #15450 | | | Definition(s) of outcome(s): Vaginal bleeding = menstrual like or heavier VB at ≥ 1 occasions > 20 wk Pregnancy-induced HTN = BP > 140/90 on ≥ 2 occasions > 20 wk in previously normotensive woman | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.83 | 0.95 | 3.53
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | Age: IVF 33.9 (4.6) IUI 32.4 (4.3) 33.3 (4.3) Race/ethnicity (n [%]): Caucasian 97% Black 0.2% Hispanic 0.9% Other 1.7% Diagnoses (n [%]): NR Inclusion criteria: All IVF & IUI pts in time frame of study Matched 5 controls per case from same geographic region within Iowa, not in infertility dbase Exclusion criteria: NR | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | 1) C-section for IVF vs spontaneous conception, singletons only: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | cs+ | cs- | Total
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | IVF | 198 | 447 | 645
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | spontaneous | 1086 | 3504 | 4590
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Total | 1284 | 3951 | 5235
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | Value | Lower 95% CI | Upper 95% CI
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Rel risk | 1.30 | 1.14 | 1.47
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | 2) C-section for IUI vs spontaneous conception, singletons only:
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | cs+ | cs- | Total
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | IUI | 198 | 447 | 645
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | spontaneous | 79 | 185 | 264
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Total | 277 | 632 | 909
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | Value | Lower 95% CI | Upper 95% CI
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Rel risk | 1.03 | 0.82 | 1.28
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | 3) PTB for IVF vs spontaneous, singleton only:
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | ptb+ | ptb- | Total
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | IVF | 10 | 635 | 645
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | spontaneous | 36 | 4554 | 4590
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Total | 46 | 5189 | 5235
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | Value | Lower 95% CI | Upper 95% CI
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Rel risk | 1.98 | 0.99 | 3.96
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | 4) PTB for IUI vs spontaneous, singletons only:
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | ptb+ | ptb- | Total
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | IUI | 6 | 258 | 264
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | spontaneous | 36 | 4554 | 4590
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Total | 42 | 4812 | 4854
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | Value | Lower 95% CI | Upper 95% CI
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Rel risk | 2.90 | 1.23 | 6.82
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | 5) LBWT for IVF vs spontaneous, singletons only:
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | lbwt+ | lbwt- | Total
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | IVF | 44 | 601 | 645
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | spontaneous | 195 | 4395 | 4590
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Total | 239 | 4996 | 5235
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | Value | Lower 95% CI | Upper 95% CI
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Rel risk | 1.61 | 1.17 | 2.20
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | 6) LBWT for IUI vs spontaneous, singletons only:
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | lbwt+ | lbwt- | Total
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | IUI | 23 | 241 | 264
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | spontaneous | 195 | 4395 | 4590
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Total | 218 | 4636 | 4854
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | Value | Lower 95% CI | Upper 95% CI
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Rel risk | 2.05 | 1.36 | 3.10
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | 7) Major birth defect for IVF vs spontaneous, all infants:
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | birth defect+ | birth defect- | Total
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | IVF | 90 | 1372 | 1462
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | spontaneous | 369 | 8053 | 8422
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Total | 459 | 9425 | 9884
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | Value | Lower 95% CI | Upper 95% CI
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Rel risk | 1.41 | 1.12 | 1.76
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | 8) Major birth defects for IUI vs spontaneous, all infants:
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | birth defect+ | birth defect- | Total
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | IUI | 17 | 326 | 343
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | spontaneous | 369 | 8053 | 8422
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | Total | 386 | 8379 | 8765
Olson, Keppler-Noreuil, Romitti, et al, 2005 #39830 | Geographical location: Iowa City, Iowa Study dates: 1989 - 2002 Size of population: # children born 1,462 IVF 343 IUI 8,422 natural conceptions Study type: Matched cohort | | Definition(s) of outcome(s): Major birth defect through 1 yr of age - cause functional impairment or require surgical correction | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.13 | 0.70 | 1.82
Ombelet, Martens, De Sutter, et al., 2006 #54580 | Geographical location: Belgium Study dates: Jan 1993–Dec 2003 Size of population (no. of patients): Singletons ART n = 12,021 Matched controls n = 12,021 Twins ART n = 3108, matched controls n = 3108 Study type: Cohort | Age: ART 29.7 (4.1) Natural 29.6 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Controlled ovarian stimulation with/without insemination; - Controls matched for maternal age, parity, year of birth, infant sex; Exclusion criteria: Higher order multiples > twins | Definition(s) of outcome(s): Preterm birth < 37 wk Low birthweight < 2500 g NICU admission Perinatal mortality = perinatal + stillbirth+neonatal deaths Intracranial bleeding Respiratory distress syndrome (RDS) | 1) Singletons, PTB: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | PTB + | PTB - | Total
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | COH | 938 | 11083 | 12021
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Natural | 514 | 11507 | 12021
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Total | 1452 | 22590 | 24042
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | Value | Lower 95% CI | Upper 95% CI
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Rel risk | 1.82 | 1.64 | 2.03
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | 2) Singletons, LBWT:
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | LBWT + | LBWT - | Total
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | COH | 794 | 11227 | 12021
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Natural | 441 | 11580 | 12021
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Total | 1235 | 22807 | 24042
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | Value | Lower 95% CI | Upper 95% CI
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Rel risk | 1.80 | 1.61 | 2.02
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | 3) Singletons, NICU admissions:
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | NICU + | NICU - | Total
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | COH | 2194 | 9827 | 12021
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Natural | 1536 | 10485 | 12021
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Total | 3730 | 20312 | 24042
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | Value | Lower 95% CI | Upper 95% CI
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Rel risk | 1.43 | 1.35 | 1.52
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | 4) Singletons, perinatal mortality:
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | Perinatal mortality + | Perinatal mortality - | Total
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | COH | 182 | 11839 | 12021
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Natural | 140 | 11881 | 12021
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Total | 322 | 23720 | 24042
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | Value | Lower 95% CI | Upper 95% CI
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Rel risk | 1.30 | 1.04 | 1.62
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | 5) Singletons, intracranial bleed:
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | IC bleed + | IC bleed - | Total
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | COH | 46 | 11975 | 12021
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Natural | 14 | 12007 | 12021
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Total | 60 | 23982 | 24042
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | Value | Lower 95% CI | Upper 95% CI
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Rel risk | 3.29 | 1.81 | 5.97
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | 6) Singletons, RDS:
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | RDS + | RDS - | Total
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | COH | 102 | 11919 | 12021
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Natural | 40 | 11981 | 12021
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Total | 142 | 23900 | 24042
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | Value | Lower 95% CI | Upper 95% CI
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Rel risk | 2.55 | 1.77 | 3.67
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | 7) Twins, preterm birth:
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | PTB + | PTB - | Total
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | COH | 1669 | 1439 | 3108
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Natural | 1602 | 1506 | 3108
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Total | 3271 | 2945 | 6216
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | Value | Lower 95% CI | Upper 95% CI
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Rel risk | 1.04 | 0.99 | 1.09
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | 8) Twins, LBWT:
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | LBWT + | LBWT - | Total
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | COH | 1762 | 1346 | 3108
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Natural | 1719 | 1389 | 3108
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Total | 3481 | 2735 | 6216
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | Value | Lower 95% CI | Upper 95% CI
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Rel risk | 1.03 | 0.98 | 1.07
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | 9) Twins, NICU admission:
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | NICU + | NICU - | Total
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | COH | 2111 | 997 | 3108
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Natural | 2119 | 989 | 3108
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Total | 4230 | 1986 | 6216
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | Value | Lower 95% CI | Upper 95% CI
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Rel risk | 1.00 | 0.96 | 1.03
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | 10) Twins, perinatal mortality:
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | Perinatal mort + | Perinatal mort - | Total
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | COH | 196 | 2912 | 3108
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Natural | 152 | 2956 | 3108
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Total | 348 | 5868 | 6216
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | Value | Lower 95% CI | Upper 95% CI
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Rel risk | 1.29 | 1.05 | 1.58
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | 11) Twins, intracranial bleed:
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | IC bleed + | IC bleed - | Total
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | COH | 61 | 3047 | 3108
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Natural | 46 | 3062 | 3108
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Total | 107 | 6109 | 6216
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | Value | Lower 95% CI | Upper 95% CI
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Rel risk | 1.33 | 0.91 | 1.94
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | 12) Twins, RDS:
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | RDS + | RDS - | Total
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | ART | 191 | 2917 | 3108
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Natural | 155 | 2953 | 3108
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | Total | 346 | 5870 | 6216
Ombelet, Martens, De Sutter, et al., 2006 #54580 | | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.23 | 1.00 | 1.51
Orlandi, Rossi, Allegra, et al., 2002 #1080 | Geographical location: Italy Study dates: Sep 1995 – Dec 2000 Size of population: ART 74 singletons, 30 twins Spontaneous 370 singletons, 150 twins Study type: Cohort | Age: Controls, singleton 31.99 (4.45) ART singletons 32.47 (3.8) Controls twins 31.34 (3.72) ART twins 31.27 (4.07) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Matched 5 controls per ART subject based on gestational age, maternal age, & time of testing Exclusion criteria: NR | Definition(s) of outcome(s): NR | 1) False+ rate for Down syndrome screening for ART vs spontaneous: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining clinical outcomes: +/- Adequate follow-up period: +/- Completeness of follow-up: +/- Analysis (multivariate adjustments) and reporting of results: -
Orlandi, Rossi, Allegra, et al., 2002 #1080 | Geographical location: Italy Study dates: Sep 1995 – Dec 2000 Size of population: ART 74 singletons, 30 twins Spontaneous 370 singletons, 150 twins Study type: Cohort | | Definition(s) of outcome(s): NR | | false+ | no false+ | Total
Orlandi, Rossi, Allegra, et al., 2002 #1080 | Geographical location: Italy Study dates: Sep 1995 – Dec 2000 Size of population: ART 74 singletons, 30 twins Spontaneous 370 singletons, 150 twins Study type: Cohort | | Definition(s) of outcome(s): NR | ART+ | 7 | 59 | 66
Orlandi, Rossi, Allegra, et al., 2002 #1080 | Geographical location: Italy Study dates: Sep 1995 – Dec 2000 Size of population: ART 74 singletons, 30 twins Spontaneous 370 singletons, 150 twins Study type: Cohort | | Definition(s) of outcome(s): NR | spontaneous | 22 | 341 | 363
Orlandi, Rossi, Allegra, et al., 2002 #1080 | Geographical location: Italy Study dates: Sep 1995 – Dec 2000 Size of population: ART 74 singletons, 30 twins Spontaneous 370 singletons, 150 twins Study type: Cohort | | Definition(s) of outcome(s): NR | Total | 29 | 400 | 429
Orlandi, Rossi, Allegra, et al., 2002 #1080 | Geographical location: Italy Study dates: Sep 1995 – Dec 2000 Size of population: ART 74 singletons, 30 twins Spontaneous 370 singletons, 150 twins Study type: Cohort | | Definition(s) of outcome(s): NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.75 | 0.78 | 3.93
Parazzini, Pelucchi, Negri, et al. 2001 #4940 | Geographical location: Italy, multi-center Study dates: Jan 1992 – Sept 1999 Size of population: 1,031 cases epithelial ovarian CA 2,411 controls Study type: Case-control | Age: Cases median 56, range 18–79 Controls median 57, range 17–79 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Admissions with histologically confirmed epithelial ovarian cancer Controls from same geographical areas, hospitalized for acute, non-neoplastic conditions Exclusion criteria: Borderline tumors Hormonal or gyn diseases, bilateral oophorectomy | Definition(s) of outcome(s): Ovarian Cancer confirmed by histological test | 1) Ovarian Cancer in fertility drug use vs no fertility drug use: | | | | Comments: None Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: - Comparability of cases and controls with respect to potential confounders: + Appropriateness of statistical analyses: +
Parazzini, Pelucchi, Negri, et al. 2001 #4940 | Geographical location: Italy, multi-center Study dates: Jan 1992 – Sept 1999 Size of population: 1,031 cases epithelial ovarian CA 2,411 controls Study type: Case-control | | Definition(s) of outcome(s): Ovarian Cancer confirmed by histological test | | Ov CA+ | Ov CA- | Total
Parazzini, Pelucchi, Negri, et al. 2001 #4940 | Geographical location: Italy, multi-center Study dates: Jan 1992 – Sept 1999 Size of population: 1,031 cases epithelial ovarian CA 2,411 controls Study type: Case-control | | Definition(s) of outcome(s): Ovarian Cancer confirmed by histological test | fertility drug use | 15 | 26 | 41
Parazzini, Pelucchi, Negri, et al. 2001 #4940 | Geographical location: Italy, multi-center Study dates: Jan 1992 – Sept 1999 Size of population: 1,031 cases epithelial ovarian CA 2,411 controls Study type: Case-control | | Definition(s) of outcome(s): Ovarian Cancer confirmed by histological test | no fertility drug use | 1016 | 2385 | 3401
Parazzini, Pelucchi, Negri, et al. 2001 #4940 | Geographical location: Italy, multi-center Study dates: Jan 1992 – Sept 1999 Size of population: 1,031 cases epithelial ovarian CA 2,411 controls Study type: Case-control | | Definition(s) of outcome(s): Ovarian Cancer confirmed by histological test | Total | 1031 | 2411 | 3442
Parazzini, Pelucchi, Negri, et al. 2001 #4940 | Geographical location: Italy, multi-center Study dates: Jan 1992 – Sept 1999 Size of population: 1,031 cases epithelial ovarian CA 2,411 controls Study type: Case-control | | Definition(s) of outcome(s): Ovarian Cancer confirmed by histological test | | Value | Lower 95% CI | Upper 95% CI
Parazzini, Pelucchi, Negri, et al. 2001 #4940 | Geographical location: Italy, multi-center Study dates: Jan 1992 – Sept 1999 Size of population: 1,031 cases epithelial ovarian CA 2,411 controls Study type: Case-control | | Definition(s) of outcome(s): Ovarian Cancer confirmed by histological test | Odds rat | 1.35 | 0.71 | 2.57
Parazzini, Pelucchi, Negri, et al. 2001 #4940 | Geographical location: Italy, multi-center Study dates: Jan 1992 – Sept 1999 Size of population: 1,031 cases epithelial ovarian CA 2,411 controls Study type: Case-control | | Definition(s) of outcome(s): Ovarian Cancer confirmed by histological test | 2) Ovarian Cancer for time since last use of fertility drugs:
Parazzini, Pelucchi, Negri, et al. 2001 #4940 | Geographical location: Italy, multi-center Study dates: Jan 1992 – Sept 1999 Size of population: 1,031 cases epithelial ovarian CA 2,411 controls Study type: Case-control | | Definition(s) of outcome(s): Ovarian Cancer confirmed by histological test | | Ov CA+ | Ov CA- | Total
Parazzini, Pelucchi, Negri, et al. 2001 #4940 | Geographical location: Italy, multi-center Study dates: Jan 1992 – Sept 1999 Size of population: 1,031 cases epithelial ovarian CA 2,411 controls Study type: Case-control | | Definition(s) of outcome(s): Ovarian Cancer confirmed by histological test | ≥ 25 yrs | 7 | 12 | 19
Parazzini, Pelucchi, Negri, et al. 2001 #4940 | Geographical location: Italy, multi-center Study dates: Jan 1992 – Sept 1999 Size of population: 1,031 cases epithelial ovarian CA 2,411 controls Study type: Case-control | | Definition(s) of outcome(s): Ovarian Cancer confirmed by histological test | < 25 yrs | 7 | 13 | 20
Parazzini, Pelucchi, Negri, et al. 2001 #4940 | Geographical location: Italy, multi-center Study dates: Jan 1992 – Sept 1999 Size of population: 1,031 cases epithelial ovarian CA 2,411 controls Study type: Case-control | | Definition(s) of outcome(s): Ovarian Cancer confirmed by histological test | Total | 14 | 25 | 39
Parazzini, Pelucchi, Negri, et al. 2001 #4940 | Geographical location: Italy, multi-center Study dates: Jan 1992 – Sept 1999 Size of population: 1,031 cases epithelial ovarian CA 2,411 controls Study type: Case-control | | Definition(s) of outcome(s): Ovarian Cancer confirmed by histological test | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.08 | 0.29 | 4.01
Perri, Chen, Yoeli, et al., 2001 #4680 | Geographical location: Tel Aviv, Israel Study dates: 1996 Size of population: 95 ART singleton pregnancies 190 matched spontaneous conceptions of total 2546 spontaneous conceptions for cohort analysis Study type: Cohort | Age: ART: 32.15 (4.5) Matched spontaneous: 32.13 (4.5) Race/ethnicity (n [%]): ART 82 Jewish, 13 Arabic Matched spontaneous 164 Jewish, 26 Arabic Diagnoses (n [%]): Unexplained infertility: 28% Endometriosis: 5% Male factor: 19% Tubal factor: 14% PCOS: 8% Other (specify): 6% 21% had > 1 indication Inclusion criteria:; - Singleton ART-derived pregnancies achieved by IVF; - ICSI; - Transferring both IVF-and ICSI-derived embryos; Exclusion criteria: NR | Definition(s) of outcome(s): PTB < 37wk | 1) PTB for ART vs. spontaneous conception in cohort analysis: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: +/- Use of validated method for ascertaining clinical outcomes: +/- Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | | PTB + | PTB - | Total
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | ART | 19 | 76 | 95
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | Spont | 185 | 2361 | 2546
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | Total | 204 | 2437 | 2641
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | | Value | Lower 95% CI | Upper 95% CI
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | Rel risk | 2.75 | 1.80 | 4.21
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | 2) PTB for ART vs. spontaneous conception in matched cohort analysis:
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | | PTB + | PTB - | Total
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | ART | 19 | 76 | 95
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | Spont | 8 | 182 | 190
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | Total | 27 | 258 | 285
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | | Value | Lower 95% CI | Upper 95% CI
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | Rel risk | 4.75 | 2.16 | 10.45
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | 3) Cesarean delivery for ART vs. spontaneous conception in matched cohort analysis:
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | | C/S + | C/S - | Total
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | ART | 40 | 55 | 95
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | Spont | 39 | 151 | 190
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | Total | 79 | 206 | 285
Perri, Chen, Yoeli, et al., 2001 #4680 | | | Definition(s) of outcome(s): PTB < 37wk | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 2.05 | 1.42 | 2.96
Pinborg, Lidegaard, Freiesleben, et al., 2007 #72240 | Geographical location: Copenhagen, Denmark Study dates: January 1995–Dec 2001 Size of population (no. of patients): 9557 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Pregnancy after ART in one of 11 Danish clinics, with ultrasound at 8 weeks showing; (i) one viable fetus plus an empty gestational sac or a fetus with no fetal heart beat,; (ii) one viable fetus or; (ii) two viable fetuses; - Vanished twin: any empty gestational sac or 1^st^, 2^nd^, or 3^rd^ trimester loss; Exclusion criteria: More than 2 heart beats or no viable fetuses | Definition(s) of outcome(s): SGA: < 10^th^ percentile for gestational age | 1) Small-for-gestational-age, survivor of vanishing twins vs. singletons: | | | | Comments: Birth weight percentiles for twins apparently not adjusted Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Pinborg, Lidegaard, Freiesleben, et al., 2007 #72240 | Geographical location: Copenhagen, Denmark Study dates: January 1995–Dec 2001 Size of population (no. of patients): 9557 Study type: Cohort | | Definition(s) of outcome(s): SGA: < 10^th^ percentile for gestational age | | Out + | Out - | Total
Pinborg, Lidegaard, Freiesleben, et al., 2007 #72240 | Geographical location: Copenhagen, Denmark Study dates: January 1995–Dec 2001 Size of population (no. of patients): 9557 Study type: Cohort | | Definition(s) of outcome(s): SGA: < 10^th^ percentile for gestational age | Survivor | 34 | 608 | 642
Pinborg, Lidegaard, Freiesleben, et al., 2007 #72240 | Geographical location: Copenhagen, Denmark Study dates: January 1995–Dec 2001 Size of population (no. of patients): 9557 Study type: Cohort | | Definition(s) of outcome(s): SGA: < 10^th^ percentile for gestational age | Singletons | 188 | 5049 | 5237
Pinborg, Lidegaard, Freiesleben, et al., 2007 #72240 | Geographical location: Copenhagen, Denmark Study dates: January 1995–Dec 2001 Size of population (no. of patients): 9557 Study type: Cohort | | Definition(s) of outcome(s): SGA: < 10^th^ percentile for gestational age | Total | 222 | 5657 | 5879
Pinborg, Lidegaard, Freiesleben, et al., 2007 #72240 | Geographical location: Copenhagen, Denmark Study dates: January 1995–Dec 2001 Size of population (no. of patients): 9557 Study type: Cohort | | Definition(s) of outcome(s): SGA: < 10^th^ percentile for gestational age | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Lidegaard, Freiesleben, et al., 2007 #72240 | Geographical location: Copenhagen, Denmark Study dates: January 1995–Dec 2001 Size of population (no. of patients): 9557 Study type: Cohort | | Definition(s) of outcome(s): SGA: < 10^th^ percentile for gestational age | Rel risk | 1.48 | 1.03 | 2.11
Adjusted OR similar; increasing age of loss also associated (OR 2.08, 95% CI 1.00–4.35 Risk for survivors substantially lower than for twins
Pinborg, Lidegaard, la Cour Freiesleben, et al., 2005 #39560 | Geographical location: Denmark Study dates: Jan 1995–Dec 2001 Size of population (no. of patients): 8251 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - ART pregnancy; - 8 week U/S with 1 viable fetus + 1 empty sac or fetus without heart beat; or 1 viable fetus; or 2 viable fetuses; Exclusion criteria:; - > 2 heart beats; - No viable fetuses | Definition(s) of outcome(s): Birthweight Prematurity Perinatal mortality | 1) Overall incidence of spontaneous reduction 10.4%. 2) Adjusted risks (95% CI) (adjusted for maternal age, parity, and mode of conception) for spontaneous reduction vs singleton pregnancies: Low birthweight (< 2500 gm): 2.0 (1.5, 2.6) VLBW (< 1500 gm): 3.0 (1.9, 4.7) Preterm delivery (< 37 weeks): 1.6 (1.2, 2.0) Very preterm (< 32 weeks): 3.0 (1.9, 4.8) Risk for neonatal death increased, but not significant after adjustment for gestational age. Trend towards increased risk for cerebral palsy. Increased risk as gestational age of loss increases. | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: - Analysis (multivariate adjustments) and reporting of results: +
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | Age: Mean (SD): Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF/ICSI twins Non-IVF/ICSI twins Exclusion criteria: Stillbirths excluded from analysis | Definition(s) of outcome(s): Delivery = liveborn or stillborn after 22wks PTB < 37wks LBW < 2500gm VLBW < 1500gm Neonatal mortality= # deaths < 28d per 1000 livebirths Infant mortality = # deaths < 1yr Major malformation = functional impairment or requires surgical correction; all else minor | 1) LBWT: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +/-
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | | LBWT+ | LBWT- | Total
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | ART twins | 1439 | 1954 | 3393
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | control twins | 4147 | 6092 | 10239
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | Total | 5586 | 8046 | 13632
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | Rel risk | 1.05 | 1.00 | 1.10
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | 2) VLBW:
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | | VLBWT+ | VLBWT- | Total
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | ART twins | 255 | 3138 | 3393
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | control twins | 696 | 9543 | 10239
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | Total | 951 | 12681 | 13632
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | Rel risk | 1.11 | 0.96 | 1.27
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | 3) PTB:
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | | PTB+ | PTB- | Total
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | ART twins | 1490 | 1903 | 3393
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | control twins | 4249 | 5990 | 10239
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | Total | 5739 | 7893 | 13632
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | Rel risk | 1.06 | 1.01 | 1.11
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | 4) Neo mortality:
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | | neo death+ | neo death- | Total
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | ART twins | 30 | 3363 | 3393
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | control twins | 141 | 10098 | 10239
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | Total | 171 | 13461 | 13632
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | Rel risk | 0.64 | 0.43 | 0.95
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | 5) Infant mortality:
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | | infant death+ | infant death- | Total
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | ART twins | 35 | 3358 | 3393
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | control twins | 54 | 10185 | 10239
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | Total | 89 | 13543 | 13632
Pinborg, Loft, Rasmussen, et al., 2004 #14030 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.96 | 1.28 | 2.99
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | ART twins compared to control twins & ART singletons | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results:
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | 1) Childhood hospitalizations:
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | | hospitalized+ | hospitalized- | Total
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | ART twins | 2367 | 1026 | 3393
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | control twins | 7122 | 3117 | 10239
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | Total | 9489 | 4143 | 13632
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | Rel risk | 1.00 | 0.98 | 1.03
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | | hospitalized+ | hospitalized- | Total
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | ART twins | 2367 | 1026 | 3393
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | ART singles | 2557 | 2573 | 5130
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | Total | 4924 | 3599 | 8523
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | Rel risk | 1.40 | 1.35 | 1.45
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | 2) Surgical procedures:
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | | surgical intervention+ | surgical intervention- | Total
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | ART twins | 361 | 3032 | 3393
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | control twins | 1145 | 9094 | 10239
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | Total | 1506 | 12126 | 13632
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | Rel risk | 0.95 | 0.85 | 1.06
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | | surgical intervention+ | surgical intervention- | Total
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | ART twins | 361 | 3032 | 3393
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | ART singles | 436 | 4694 | 5130
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | Total | 797 | 7726 | 8523
Pinborg, Loft, Rasmussen, et al., 2004 #10840 | Geographical location: Denmark national registries Study dates: Jan 1995–Dec 2000 Size of population: IVF/ICSI twins 3,393 Control twins 10,239 IVF/ICSI singletons 5,130 Study type: Cohort | Age: Maternal age Ivf/icsi twins 33.1 (3.7) Control twins 30.5 (4.5) Ivf/icsi singles 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Up to 7 yrs of age:; - Child hospitalizations; - Surgical procedures; Term birth ≥ 37wk Neonatal admission within 1^st^ 28d of life | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.25 | 1.10 | 1.43
Pinborg, Loft, Schmidt, et al., 2003 #16610 | Geographical location: Copenhagen, Denmark Study dates: Jan–Dec 1997 Size of population: 1769 questionnaires mailed, 1436 returned 236 IVF/ICSI twins, 634 IVF/ICSI singletons, 566 non-IVF/ICSI twins Study type: Case-control Questionnaire sent to all twin mothers and IVF/ICSI singleton mothers who delivered in Denmark in 1997. Questions related to demographics, infertility hx, pregnancy outcomes, childhood morbidities, impact on mother's life | Age: Mean (SD): IVF/ICSI twin moms 33.1 (3.5) IVF/ICSI singletons 34.1 (3.5) Non-IVF/ICSI moms 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Identified women who delivered twins in 1997 through Danish Medical Birth Registry, cross-referenced with IVF registry to separate into cases/controls. Also included IVF/ICSI singletons. Exclusion criteria: See above | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | Compared to IVF/ICSI twins, IVF/ICSI singletons had lower risk of special needs (OR 0.6 [0.4–0.9]), non-IVF/ICSI twins had higher (1.1 [0.8–1.6]). | | | | Comments:; - Response rate 81%; - Analyzed non-responders - only important difference was in 2 control groups: higher mortality rate in singleton and twin control group non-respondents than respondents; - Included stillbirths, neonatal deaths; - IVF moms older, of lower parity; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: - Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | Influence on marital relationship, etc; crude data NR; multiple logistic regression used. Twins were predictor of more marital stress, less marital benefit; but the only predictors of high risk of divorce/separation were “no IVF/ICSI” and age > 30 y. Twins, nulliparity, BW < 1500 g, age < 30 y were associated with infant having high impact on mother's personal & social life.
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | 1) NICU admissions:
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | | NICU + | NICU - | Total
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | IVF twin | 181 | 273 | 454
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | Spont twin | 421 | 697 | 1118
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | Total | 602 | 970 | 1572
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | Odds rat | 1.10 | 0.88 | 1.37
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | 2) Special needs:
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | | Special needs + | Special needs - | Total
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | IVF twin | 45 | 409 | 454
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | Spont twin | 120 | 998 | 1118
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | Total | 165 | 1407 | 1572
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | Odds rat | 0.92 | 0.64 | 1.31
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | | Special needs + | Special needs - | Total
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | IVF twin | 45 | 409 | 454
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | IVF singleton | 38 | 588 | 626
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | Total | 83 | 997 | 1080
Pinborg, Loft, Schmidt, et al., 2003 #16610 | | | Definition(s) of outcome(s): NICU admission “Special needs” = speech therapy, physiotherapy, occupational therapy, or educational support | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.70 | 1.09 | 2.67
Pinborg, Loft, Schmidt, et al., 2003 #17310 | Geographical location: Copenhagen, Denmark Study dates: 1995 - 2000 Size of population: 266 IVF/ICSI twin mothers 764 IVF/ICSI singleton mothers 739 non-IVF/ICSI twin mothers Study type: Other Questionnaire sent (in 2001) to all IVF/ICSI mothers who gave birth in 1997, to assess perceptions of singletons vs twins, and single embryo transfer (SET) | Age: Mean (SD): IVF/ICSI twins 33.1 (3.5) Singletons 34.1 (3.5) Non-IVF/ICSI twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Identified women who delivered twins in 1997 through Danish Medical Birth Registry, cross-referenced with IVF registry to separate into cases/ctrls. Also included IVF/ICSI singletons. Exclusion criteria: See above | Definition(s) of outcome(s): Questionnaire assessed perceptions toward twins and attitudes toward SET; were advised on risk that twin preg carries to mother & child, & nearly 40% of IVF children are twins. Asked whether they found singleton or twins most desirable (before & after preg), and why. | Delivery of at least one child with VLBW was predictive of agreement to SET | | | | Comment:; - Response rate 81%; - Analyzed nonresponders - only important difference was in 2 control grps: higher mortality rate in singleton and twin control grp nonrespondents than respondents.; - Included stillbirths, neonatal deaths; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: - Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Pinborg, Loft, Schmidt, et al., 2003 #17310 | | | | >5yr of infertility was predictive of disagreement to SET.
Pinborg, Loft, Schmidt, et al., 2003 #17310 | | | | 1) Would prefer to have twins; IVF moms vs spont moms:
Pinborg, Loft, Schmidt, et al., 2003 #17310 | | | | | Prefer twins | Not prefer twins | Total
Pinborg, Loft, Schmidt, et al., 2003 #17310 | | | | IVF twin mom | 200 | 36 | 236
Pinborg, Loft, Schmidt, et al., 2003 #17310 | | | | Spont twin mom | 334 | 232 | 566
Pinborg, Loft, Schmidt, et al., 2003 #17310 | | | | Total | 534 | 268 | 802
Pinborg, Loft, Schmidt, et al., 2003 #17310 | | | | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Schmidt, et al., 2003 #17310 | | | | Odds rat | 3.86 | 2.61 | 5.71
Pinborg, Loft, Schmidt, et al., 2003 #17310 | | | | 2) Disagree with SET, vs agree or neither agree nor disagree:
Pinborg, Loft, Schmidt, et al., 2003 #17310 | | | | | Disagree SET | Other | Total
Pinborg, Loft, Schmidt, et al., 2003 #17310 | | | | IVF twin mom | 157 | 79 | 236
Pinborg, Loft, Schmidt, et al., 2003 #17310 | | | | IVF singleton | 473 | 161 | 634
Pinborg, Loft, Schmidt, et al., 2003 #17310 | | | | Total | 630 | 240 | 870
Pinborg, Loft, Schmidt, et al., 2003 #17310 | | | | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 0.68 | 0.49 | 0.94
Pinborg, Loft, Schmidt, et al., 2004 #14280 | Geographical location: Denmark Study dates: Jan–Dec 1997 Size of population: 1436/1769 questionnaires mailed (81% response rate) 236 ART twins 566 control twins 634 ART singletons Respondents + non-respondents 538 ART twins 1496 control twins Study type: Retrospective cohort via national survey questionnaire via mail and national birth registry | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | Odds ratios given for maternal conditions in ART vs. control twins, stratified by age & parity; no raw numbers given | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | Preeclampsia 1.0 [0.5, 1.7]
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | GDM 1.9 [0.9, 4.0]
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | Results for respondents only
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | BIRTH OUTCOMES OBTAINED FROM REGISTRY, SO RESPONDENTS + NONRESPONDENTS INCLUDED
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | 1) LBW < 2500 g:
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | | LBW + | LBW - | Total
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | ART twins | 94 | 444 | 538
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | Control twins | 215 | 1281 | 1496
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | Total | 309 | 1725 | 2034
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | Rel risk | 1.22 | 0.97 | 1.52
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | 2) PTB < 37 wk:
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | | PTB + | PTB - | Total
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | ART twins | 123 | 415 | 538
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | Control twins | 280 | 1216 | 1496
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | Total | 403 | 1631 | 2034
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | Rel risk | 1.22 | 1.01 | 1.47
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | 3) Neonatal mortality:
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | | Neo death + | Neo death - | Total
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | ART twins | 18 | 520 | 538
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | Control twins | 33 | 1463 | 1496
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | Total | 51 | 1983 | 2034
Pinborg, Loft, Schmidt, et al., 2004 #14280 | | Age: Mean (SD): ART twins 33.1 (3.5) Control twins 30.5 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Registry identification Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia & GDM based on physician diagnosis as recorded in registry PTB < 37 wk LBW < 2500 g | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.52 | 0.86 | 2.67
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | Age: Mean (SD): Art twins 33.1 (3.7) Control twins 30.5 (4.5) Art singletons 33.8 (3.7) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Danish medical birth registry Exclusion criteria: NR | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | 1) CP in twins only: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining clinical outcomes: +/- Adequate follow-up period: +/- Completeness of follow-up: +/- from 2–7 years of age, 2 is probably too young to accurately eliminate abnl neuro condition Analysis (multivariate adjustments) and reporting of results: +
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | | CP+ | CP- | Total
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | ART twins | 11 | 3382 | 3393
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | control twins | 41 | 10198 | 10239
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | Total | 52 | 13580 | 13632
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | Rel risk | 0.81 | 0.42 | 1.57
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | 2) MR in twins only:
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | | MR+ | MR- | Total
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | ART twins | 4 | 3389 | 3393
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | control twins | 14 | 10225 | 10239
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | Total | 18 | 13614 | 13632
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | Rel risk | 0.86 | 0.28 | 2.62
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | 3) Retarded psychomotor dev twins only:
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | | pmotor+ | pmotor- | Total
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | ART twins | 12 | 3381 | 3393
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | control twins | 32 | 10207 | 10239
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | Total | 44 | 13588 | 13632
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | | Value | Lower 95% CI | Upper 95% CI
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | Rel risk | 1.13 | 0.58 | 2.19
Pinborg, Loft, Schmidt, et al., 2004 #10120 | Geographical location: Denmark Study dates: 1995 - 2000 Size of population: ART 3393 twins, 5130 singletons Spontaneous twins 10239 Study type: Cohort | | Definition(s) of outcome(s): ICD-10 codes for following disease outcomes - no further definitions given Cerebral palsy (CP) Mental retardation (MR) Retarded psychomotor development | 4) OR neuro sequelae IVF vs ICSI twins + singletons (raw #s not provided)
0.9 [0.5, 1.7]
Place and Englert, 2003 #14630 | Geographical location: Brussels, Belgium Study dates: April 1998 – March 2000 Size of population: ICSI = 66 IVF = 52 Spont = 59 Study type: Cohort Compared ICSI-conceived children with children conceived by conventional IVF, and with spontaneously-conceived children wrt somatic, psychomotor, and intellectual development over preschool period. Controls matched for birthdate, age & sex of child, maternal age, social class, ethnic background, family size, and birth order of child. Children seen at 2 of these timepoints: 9 mos, 18 mos, 3y, and/or 5y. Assessments performed by same clinical psychologist, in homes. Questionnaire also filled out by child's pediatrician. | Age: Mean (SD): 31.9 (3.78) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Spont - families who gave birth to fullterm singletons at Erasme Hosp were contacted. ICST & IVF - head of fertility clinic wrote to families after birth, asked for consent. At least one partner Belgian, other European & residing in Belgium >=3y Exclusion criteria: Pregnancies after frozen or thawed ET's, children with birthwt <2500g | Definition(s) of outcome(s): Major malformation = requiring surgical correction or causing functional impairment. Brunet -Lezine scale used to assess developmental function; yields developmental quotient (DQ), with mean score of 100. Done at 9 & 18 mos. Wechsler preschool & primary scales of intelligence (WPPSI-R) to assess intellect at 3 & 5y (IQ). | No difference in maj malform, need for NICU care, health problems at all ages, longterm hospitalization, DQ (and no child showed significant delay). | | | | Comments:; - Acceptance rate 70% for ICSI, 60% for IVF, 40% spont.; - F/u rate 91% for ICSI, 93% for IVF, 84% for spont; Parents of spont grp had higher levels of education.; - Data collected prospectively; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: + Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Place and Englert, 2003 #14630 | | | | Mean IQ at 3&5y significantly lower for IVF & ICSI grps than spont, but this difference disappeared after adjustment for parental education level.
Place and Englert, 2003 #14630 | | | | 1) Cesarean; no diff btw any of 3 grps:
Place and Englert, 2003 #14630 | | | | | C/S | No C/S | Total
Place and Englert, 2003 #14630 | | | | ICSI | 13 | 53 | 66
Place and Englert, 2003 #14630 | | | | Spont | 7 | 52 | 59
Place and Englert, 2003 #14630 | | | | Total | 20 | 105 | 125
Place and Englert, 2003 #14630 | | | | | Value | Lower 95% CI | Upper 95% CI
Place and Englert, 2003 #14630 | | | | Rel risk | 1.66 | 0.71 | 3.88
Place and Englert, 2003 #14630 | | | | 2) IQ at 3yo:
Place and Englert, 2003 #14630 | | | | | IQ < 85 | IQ ≥ 85 | Total
Place and Englert, 2003 #14630 | | | | ICSI | 6 | 25 | 31
Place and Englert, 2003 #14630 | | | | Spont | 2 | 25 | 27
Place and Englert, 2003 #14630 | | | | Total | 8 | 50 | 58
Place and Englert, 2003 #14630 | | | | | Value | Lower 95% CI | Upper 95% CI
Place and Englert, 2003 #14630 | | | | Rel risk | 2.61 | 0.57 | 11.89
Place and Englert, 2003 #14630 | | | | | IQ < 85 | IQ ≥ 85 | Total
Place and Englert, 2003 #14630 | | | | IVF | 7 | 12 | 19
Place and Englert, 2003 #14630 | | | | Spont | 2 | 25 | 27
Place and Englert, 2003 #14630 | | | | Total | 9 | 37 | 46
Place and Englert, 2003 #14630 | | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 4.97 | 1.16 | 21.37
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | Geographical location: Helsinki, Finland Study dates: 1997-2003 Size of population (no. of patients): 499 ART, 15,037 Study type: Cohort Single embryo transfer vs. singleton after double embryo transfer vs. spontaneous singleton | Age: Mean (SD): SET 32.6 (3.9) DET 34.2 (3.8) Spont 30.3 (5.3) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Exposed: Singleton pregnancy after IVF/ICSI at clinic; - Control: 10% sample of all births in Finland matched for year of delivery, maternal place of residence; Exclusion criteria:; - PGD; - Delivery outside of Finland | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | 1) Delivery prior to 37 weeks, single embryo transfer vs. spontaneous: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | | < 37 weeks | ≥ 37 weeks | Total
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | SET | 33 | 236 | 269
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Spont- | 666 | 14371 | 15037
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Total | 699 | 14607 | 15306
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | | Value | Lower 95% CI | Upper 95% CI
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Rel risk | 2.77 | 2.00 | 3.85
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | 2) Delivery prior to 37 weeks, singleton after double embryo transfer vs. spontaneous:
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | | < 37 weeks | ≥ 37 weeks | Total
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | DET | 26 | 204 | 230
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Spont- | 666 | 14371 | 15037
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Total | 692 | 14575 | 15267
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | | Value | Lower 95% CI | Upper 95% CI
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Rel risk | 2.55 | 1.76 | 3.69
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | 3) SGA, single embryo transfer vs. spontaneous:
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | | SGA+ | SGA - | Total
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | SET | 10 | 259 | 269
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Spont | 314 | 14723 | 15037
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Total | 324 | 14982 | 15306
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | | Value | Lower 95% CI | Upper 95% CI
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Rel risk | 1.78 | 0.96 | 3.30
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | 4) SGA, double embryo transfer vs. spontaneous:
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | | SGA+ | SGA - | Total
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | DET | 10 | 220 | 230
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Spont | 314 | 14723 | 15037
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Total | 324 | 14943 | 15267
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | | Value | Lower 95% CI | Upper 95% CI
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Rel risk | 2.08 | 1.12 | 3.85
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | 5) Adjusted for maternal age, parity, socioeconomic status:
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Preterm birth
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | SET versus spontaneous 2.85 (1.96–4.16)
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | DET versus spontaneous 2.63 (1.73–4.00)
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | SET versus DET 0.99 (0.56–1.75)
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Low birthweight
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | SET versus spontaneous 2.01 (1.19–3.99)
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | DET versus spontaneous 3.46 (2.20–5.46)
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | SET versus DET 1.74 (0.87–3.48)
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | SGA
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | SET versus spontaneous 1.42 (0.74–2.71)
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | DET versus spontaneous 1.59 (0.83–3.08)
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | SET versus DET 1.07 (0.43–2.69)
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | Low Apgar score
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | SET versus spontaneous 1.96 (1.01–2.82)
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | DET versus spontaneous 1.75 (1.01–3.04)
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | SET versus DET 1.01 (0.47–2.17)
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | NICU admission
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | SET versus spontaneous 1.96 (0.96–4.01)
Poikkeus, Gissler, Unkila-Kallio, et al., 2007 #72250 | | | Definition(s) of outcome(s): Pregnancy complications Birth weight Preterm delivery Neonatal | DET versus spontaneous 2.23 (1.08–4.58)
SET versus DET 1.46 (0.51–4.14)
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | Age: Mean (SD): ART: 33.0 (4.2) Control: 33.3 (4.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 26% Male factor: 27% All female: 33% Mixed: 20% Inclusion criteria: Finnish speaking ART:; - Volunteering Finnish-speaking; - Confirmed viable singleton pregnancy after either fresh or frozen IVF or; - ICSI with their own gametes; Exclusion criteria: Controls:; - Previous infertility; - Previous infertility treatment; - Maternal age < 25 years | Definition(s) of outcome(s): Anxiety regarding pregnancy/childbirth using two validated instruments:; - Fear-of-Childbirth Questionnaire; - Pregnancy Anxiety Score; “Severe” defined as ≥ 90^th^ percentile on each scale | 1) Severe fear of childbirth: | | | | Comments: Control selection well-described Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | | | | Severe Fear | < 90^th^ %ile | Total
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | | | IVF | 42 | 325 | 367
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | | | Spontaneous | 40 | 339 | 379
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | | | Total | 82 | 664 | 746
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | | | Rel risk | 1.08 | 0.72 | 1.63
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | | | 2) Severe Pregnancy-related anxiety:
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | | | | Severe Fear | < 90^th^ %ile | Total
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | | | IVF | 46 | 323 | 369
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | | | Spontaneous | 38 | 341 | 379
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | | | Total | 84 | 664 | 748
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | | | Rel risk | 1.24 | 0.83 | 1.86
Poikkeus, Saisto, Unkila-Kallio, et al., 2006 #54990 | Geographical location: Helsinki, Finland Study dates: 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | | | 3) Results between IVF, control groups similar when stratified by parity. Prevalence of severe scores significantly higher in nulliparous controls compared to parous controls.
4) ART not significant predictor in multivariate analysis; risk of severe fear of pregnancy increased with duration of infertility, decreased with number of ART cycles.
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | Age: ART 33.0 (4.1) Controls 33.3 (3.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Male factor: 88 (27%) Female factor 107 (33%). Combined 61 (19%) Unexplained 68 (21'%) Inclusion criteria:; - Finnish-speaking; - Viable pregnancy after fresh/frozen IVF+/-ICSI with own gametes; Exclusion criteria: Controls excluded if h/o infertility or < 25 yr old | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | 1) Preterm birth (spontaneous + medically induced): | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | | PTB + | PTB - | Total
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | ART | 21 | 303 | 324
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | Natural | 9 | 295 | 304
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | Total | 30 | 598 | 628
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | | Value | Lower 95% CI | Upper 95% CI
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | Rel risk | 2.19 | 1.02 | 4.70
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | 2) Cesarean delivery
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | | C/S + | C/S - | Total
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | ART | 85 | 239 | 324
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | Natural | 58 | 246 | 304
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | Total | 143 | 485 | 628
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | | Value | Lower 95% CI | Upper 95% CI
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | Rel risk | 1.38 | 1.02 | 1.85
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | 3) LBWT:
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | | LBWT + | LBWT - | Total
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | ART | 14 | 310 | 324
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | Natural | 4 | 300 | 304
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | Total | 18 | 610 | 628
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | | Value | Lower 95% CI | Upper 95% CI
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | Rel risk | 3.28 | 1.09 | 9.87
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | 4) NICU admission:
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | | NICU + | NICU - | Total
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | ART | 12 | 312 | 324
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | Natural | 5 | 299 | 304
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | Total | 17 | 611 | 628
Poikkeus, Unkila-Kallio, Vilska, et al., 2006 #55000 | Geographical location: Finland Study dates: 1999 Size of population (no. of patients): All singletons ART N = 324 Controls N = 304 Study type: Cohort | | Definition(s) of outcome(s): Preterm birth < 37wks Cesarean delivery | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 2.25 | 0.80 | 6.32
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | Age: Mean (SD): IVF 34.6 (4.2), ov stim 31.3 (3), spont 30.9 (4.8) Race/ethnicity (n [%]): IVF 100% white, ov stim 94.1%, spont 69.3% Diagnoses (n [%]): NR Inclusion criteria: Twin pregnancies where 2 live neonates delivered >20w Exclusion criteria: Pregnancies reduced to twins, twin gestations that delivered single liveborn | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | No diff in C/S, antepartum complications, prematurity, LBW, VLBW, growth discordance, NICU admission | | | | Comments:; - Women in IVF grp older, more often primiparous.; - Those in ov stim grp more often had poor obstetric hx (previous preg loss or preterm delivery).; - More mono/di twins in spont grop.; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: + Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | 1) C/S:
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | | C/S | no C/S | Total
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | IVF | 35 | 25 | 60
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | Spont | 60 | 41 | 101
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | Total | 95 | 66 | 161
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | | Value | Lower 95% CI | Upper 95% CI
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | Rel risk | 0.98 | 0.75 | 1.28
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | | C/S | no C/S | Total
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | ov stim | 20 | 14 | 34
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | Spont | 60 | 41 | 101
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | Total | 80 | 55 | 135
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | | Value | Lower 95% CI | Upper 95% CI
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | Rel risk | 0.99 | 0.72 | 1.37
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | 2) LBW:
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | | LBW | not LBW | Total
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | IVF | 35 | 25 | 60
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | Spont | 83 | 18 | 101
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | Total | 118 | 43 | 161
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | | Value | Lower 95% CI | Upper 95% CI
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | Rel risk | 0.71 | 0.56 | 0.90
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | | LBW | not LBW | Total
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | ov stim | 22 | 12 | 34
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | Spont | 83 | 18 | 101
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | Total | 105 | 30 | 135
Putterman, Figueroa, Garry, et al. 2003 #14420 | Geographical location: Mineola, NY Study dates: Jan 1999 – Dec 2000 Size of population: 195 twin pregnancies (60 IVF, 34 ov stim, 101 spont) Study type: Cohort (retrospective) | | Definition(s) of outcome(s): LBW < 2500g VLBW < 1500g SGA < 10%ile based on twin norms Growth discordance >20% in birthwt | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.79 | 0.60 | 1.03
Puumala, Ross, Olshan, et al., 2007 #72320 | Geographical location: US (multiple sites) Study dates: Jan 1997–Oct 2002 Size of population (no. of patients): 159 cases, 173 controls Study type: Case-control | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Cases: Down's syndrome with a diagnosis of acute lymphocytic or myeloblastic leukemia ≤19 years at diagnosis; - telephone in their residence,; - biologic mother available who spoke English,; - resided in the United State or Canada at diagnosis; Controls: Down's syndrome without leukemia seen by same primary physicians as cases Exclusion criteria: NR | Definition(s) of outcome(s): Acute myeloblastic or lymphocytic leukemia | 1) Adjusted OR (maternal age, gender, race, education) for “Ever history of trying >12 months for conception” and AML: 2.22 (1.14–4.33) However, risk not significantly increased with index pregnancy: Not trying (reference) 1.00 Trying < 12 months 1.39 (0.72–2.69) Trying > 12 months 2.11 (0.73–6.14) | | | | Comments:; - 25% of identified cases (n = 210) did not participate; - Unclear biological or clinical significance of discriminating between “not trying” and “trying < 12 months”; crude OR when both groups combined as reference 1.26 (0.49, 3.24); Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Comparability of cases and controls with respect to potential confounders: + Appropriateness of statistical analyses: +
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | 1) Singletons, PTB: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: - Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: +/- Analysis (multivariate adjustments) and reporting of results: -
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | | PTB + | PTB - | Total
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | IVF | 3 | 50 | 53
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | IVF/ICSI | 18 | 85 | 103
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | Total | 21 | 135 | 156
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | | Value | Lower 95% CI | Upper 95% CI
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | Rel risk | 0.32 | 0.10 | 1.05
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | 2) Twins, PTB:
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | | PTB + | PTB - | Total
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | IVF | 40 | 10 | 50
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | IVF/ICSI | 35 | 12 | 47
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | Total | 75 | 22 | 97
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | | Value | Lower 95% CI | Upper 95% CI
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | Rel risk | 1.07 | 0.86 | 1.34
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | 3) Singletons, LBWT:
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | | LBWT + | LBWT - | Total
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | IVF | 3 | 50 | 53
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | IVF/ICSI | 16 | 87 | 103
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | Total | 19 | 137 | 156
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | | Value | Lower 95% CI | Upper 95% CI
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | Rel risk | 0.36 | 0.11 | 1.20
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | 4) Twins, LBWT:
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | | LBWT + | LBWT - | Total
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | IVF | 42 | 8 | 50
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | IVF/ICSI | 34 | 13 | 47
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | Total | 76 | 21 | 97
Rajesh, Yap, and Wu, 2006 #55140 | Geographical location: Singapore Study dates: 1999-2003 Size of population (no. of patients): IVF +/- ICSI n = 271 Study type: Cohort | Age: Mean: IVF: 33.4 ICSI: 33.7 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF +/-r ICSI during study period Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37 wks Low BWT < 2500 g Cesarean not separated by plurality | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.16 | 0.94 | 1.44
Raty, Virtanen, Koskinen, et al., 2000 #8300 | Geographical location: Turku, Oulu, Tampere, and Helsinki, Finland Study dates: 1994-1996 Size of population (no. of patients): 6548 singleton pregnancies (unclear if all spontaneous or some ART) 145 spontaneous twins 30 IVF twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Multiples of median for AFP (n < 100 for free β-hCG) APF drawn 14–18 weeks | 1) Multiples of median, AFP (95% CIs): Singleton: 1.00 (0.57,1.79) Spontaneous twins: 2.18 (1.24, 3.84) IVF twins: 2.30 (1.29, 4.68) | | | | Comments: Test positive rate not reported Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: - Use of validated method for ascertaining exposure: - Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: + Completeness of follow-up: - Analysis (multivariate adjustments) and reporting of results: -
Raziel, Friedler, Schachter, et al., 2002 #3030 | Geographical location: Israel Study dates: Jan 1994–Dec 1999 Size of population: 104 Study type: Cohort | Age: Pregnant 28 (4.5) Non-pregnant 29.4 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF; - Hospitalization for OHSS; Exclusion criteria: No embryo transfer performed | Definition(s) of outcome(s): Outcomes not defined | 1) Pregnancy rate in OHSS vs no OHSS: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: - Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: + Completeness of follow-up: +/- Analysis (multivariate adjustments) and reporting of results: -
Raziel, Friedler, Schachter, et al., 2002 #3030 | Geographical location: Israel Study dates: Jan 1994–Dec 1999 Size of population: 104 Study type: Cohort | Age: Pregnant 28 (4.5) Non-pregnant 29.4 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF; - Hospitalization for OHSS; Exclusion criteria: No embryo transfer performed | Definition(s) of outcome(s): Outcomes not defined | | Preg + | Preg - | Total
Raziel, Friedler, Schachter, et al., 2002 #3030 | Geographical location: Israel Study dates: Jan 1994–Dec 1999 Size of population: 104 Study type: Cohort | Age: Pregnant 28 (4.5) Non-pregnant 29.4 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF; - Hospitalization for OHSS; Exclusion criteria: No embryo transfer performed | Definition(s) of outcome(s): Outcomes not defined | OHSS + | 60 | 44 | 104
Raziel, Friedler, Schachter, et al., 2002 #3030 | Geographical location: Israel Study dates: Jan 1994–Dec 1999 Size of population: 104 Study type: Cohort | Age: Pregnant 28 (4.5) Non-pregnant 29.4 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF; - Hospitalization for OHSS; Exclusion criteria: No embryo transfer performed | Definition(s) of outcome(s): Outcomes not defined | OHSS - | 1138 | 3784 | 4922
Raziel, Friedler, Schachter, et al., 2002 #3030 | Geographical location: Israel Study dates: Jan 1994–Dec 1999 Size of population: 104 Study type: Cohort | Age: Pregnant 28 (4.5) Non-pregnant 29.4 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF; - Hospitalization for OHSS; Exclusion criteria: No embryo transfer performed | Definition(s) of outcome(s): Outcomes not defined | Total | 1198 | 3828 | 5026
Raziel, Friedler, Schachter, et al., 2002 #3030 | Geographical location: Israel Study dates: Jan 1994–Dec 1999 Size of population: 104 Study type: Cohort | Age: Pregnant 28 (4.5) Non-pregnant 29.4 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF; - Hospitalization for OHSS; Exclusion criteria: No embryo transfer performed | Definition(s) of outcome(s): Outcomes not defined | | Value | Lower 95% CI | Upper 95% CI
Raziel, Friedler, Schachter, et al., 2002 #3030 | Geographical location: Israel Study dates: Jan 1994–Dec 1999 Size of population: 104 Study type: Cohort | Age: Pregnant 28 (4.5) Non-pregnant 29.4 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF; - Hospitalization for OHSS; Exclusion criteria: No embryo transfer performed | Definition(s) of outcome(s): Outcomes not defined | Rel risk | 2.50 | 2.10 | 2.96
Raziel, Friedler, Schachter, et al., 2002 #3030 | Geographical location: Israel Study dates: Jan 1994–Dec 1999 Size of population: 104 Study type: Cohort | Age: Pregnant 28 (4.5) Non-pregnant 29.4 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF; - Hospitalization for OHSS; Exclusion criteria: No embryo transfer performed | Definition(s) of outcome(s): Outcomes not defined | 2) SAb rate in OHSS vs. no OHSS:
Raziel, Friedler, Schachter, et al., 2002 #3030 | Geographical location: Israel Study dates: Jan 1994–Dec 1999 Size of population: 104 Study type: Cohort | Age: Pregnant 28 (4.5) Non-pregnant 29.4 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF; - Hospitalization for OHSS; Exclusion criteria: No embryo transfer performed | Definition(s) of outcome(s): Outcomes not defined | | Sab + | Sab - | Total
Raziel, Friedler, Schachter, et al., 2002 #3030 | Geographical location: Israel Study dates: Jan 1994–Dec 1999 Size of population: 104 Study type: Cohort | Age: Pregnant 28 (4.5) Non-pregnant 29.4 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF; - Hospitalization for OHSS; Exclusion criteria: No embryo transfer performed | Definition(s) of outcome(s): Outcomes not defined | OHSS + | 23 | 37 | 60
Raziel, Friedler, Schachter, et al., 2002 #3030 | Geographical location: Israel Study dates: Jan 1994–Dec 1999 Size of population: 104 Study type: Cohort | Age: Pregnant 28 (4.5) Non-pregnant 29.4 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF; - Hospitalization for OHSS; Exclusion criteria: No embryo transfer performed | Definition(s) of outcome(s): Outcomes not defined | OHSS - | 169 | 969 | 1138
Raziel, Friedler, Schachter, et al., 2002 #3030 | Geographical location: Israel Study dates: Jan 1994–Dec 1999 Size of population: 104 Study type: Cohort | Age: Pregnant 28 (4.5) Non-pregnant 29.4 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF; - Hospitalization for OHSS; Exclusion criteria: No embryo transfer performed | Definition(s) of outcome(s): Outcomes not defined | Total | 192 | 1006 | 1198
Raziel, Friedler, Schachter, et al., 2002 #3030 | Geographical location: Israel Study dates: Jan 1994–Dec 1999 Size of population: 104 Study type: Cohort | Age: Pregnant 28 (4.5) Non-pregnant 29.4 (4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - IVF; - Hospitalization for OHSS; Exclusion criteria: No embryo transfer performed | Definition(s) of outcome(s): Outcomes not defined | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 2.58 | 1.82 | 3.66
Reefhuis, Honein, Shaw, et al., 2003 #16850 | Geographical location: San Francisco, Santa Clara, CA Atlanta, GA Iowa Study dates: Infants born: Jan 1993 – Jul 1996 (CA) Jan 1993 – Aug 1997 (GA) Jan 1993 – Dec 1995 (IA) Size of population: 99 cases, 777controls Study type: Case-control Used telephone interview, standard interview instrument | Age: Mean (SD): 28.3 cases, 28.2 controls Race/ethnicity (n [%]): Cases 88% white, ctrls 64% white Diagnoses (n [%]): NR Inclusion criteria: Database of birth defects reviewed for infants with craniosynostosis. Controls were liveborn infants with no major birth defects Exclusion criteria: Infants with chromosomal anomalies or recognized syndromes, mothers with first-degree family history of craniosynostosis, mothers who did not speak English or Spanish. | Definition(s) of outcome(s): Case records were reviewed by clinical geneticist & classified as isolated or assoc w/1 or more other unrelated birth defects. Use of ovulation stimulation = reported use from 3 mos before until 3 mos after conception | Crude data are below. | | | | Comments: Relied on maternal reports of fertility assistance use Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: + Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | Analyses on subgrps done for potential confounders (mat age, white mat race, singleton births, nonsmoking mothers), but data too sparse to allow for simultaneous adjustment. Stronger association between CC and craniosynostosis in younger mothers (OR 5.5 [1.1–23.5]) & nonsmokers (OR 4.5 [1.2–14.8]).
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | 1) Use of any fertility assistance:
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | | cases | ctrls | Total
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | any fert assist | 10 | 89 | 99
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | none | 31 | 744 | 775
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | Total | 41 | 833 | 874
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | | Value | Lower 95% CI | Upper 95% CI
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | Odds rat | 2.70 | 1.28 | 5.69
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | 2) Use of clomiphene citrate:
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | | cases | ctrls | Total
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | CC only | 5 | 89 | 94
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | none | 14 | 753 | 767
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | Total | 19 | 842 | 861
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | | Value | Lower 95% CI | Upper 95% CI
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | Odds rat | 3.02 | 1.06 | 8.59
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | 3) Use of artificial insemination:
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | | cases | ctrls | Total
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | AI | 3 | 89 | 92
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | none | 6 | 753 | 759
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | Total | 9 | 842 | 851
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | | Value | Lower 95% CI | Upper 95% CI
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | Odds rat | 4.23 | 1.04 | 17.21
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | These CI's are a little different from published
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | 4) Use of ART:
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | | cases | ctrls | Total
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | ART | 2 | 89 | 91
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | none | 4 | 753 | 757
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | Total | 6 | 842 | 848
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | | Value | Lower 95% CI | Upper 95% CI
Reefhuis, Honein, Shaw, et al., 2003 #16850 | | | | Odds rat | 4.23 | 0.76 | 23.43
These CI's are a little different from published
Repokari, Punamaki, Poikkeus, et al., 2006 #55210 | Geographical location: Helsinki, Finland Study dates: Recruited during 1999 Size of population (no. of patients): ART: 367, control: 379 Study type: Cohort | Age: Mean (SD): ART: 33.0 (4.2) Control: 33.3 (4.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 26% Male factor: 27% All female: 33% Mixed: 20% Inclusion criteria: Finnish speaking ART:; - Volunteering Finnish-speaking; - Confirmed viable singleton pregnancy after either fresh or frozen IVF or; - ICSI with their own gametes; Exclusion criteria: Controls:; - Previous infertility; - Previous infertility treatment; - Maternal age < 25 years | Definition(s) of outcome(s): Questionnaires filled out by both parents; - 2^nd^ trimester; - child aged 2 months; - child aged 12 months; Instruments included: Parenting Stress Index (Abidin) | 1) Mother: Scores for overall parenting higher for ART group; increased significantly from 2 months to 12 months for ART group but not for control. 2) Obstetric risk factors and problems, difficult child characteristics negatively associated with parenting in control group but not ART group. | | | | Comments: Same population as Poikkeus, Saisto, Unkila-Kallio, et al., 2006 (#54990) Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Repokari, Punamaki, Unkila-Kallio, et al., 2007 #72370 | Geographical location: Helsinki, Oulu, and Turu, Finland Study dates: NR Size of population (no. of patients): 367 singleton pregnancies after ART, 379 singleton pregnancies after spontaneous conception Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Finnish-speaking couples who had viable pregnancies after ART (fresh or frozen embryo transfer after IVF or ICSI treatment with their own gametes) during 1999 at five infertility clinics in Finland; - Controls recruited from couples undergoing routine second trimester ultrasound at Helsinki hospital; Exclusion criteria: NR | Definition(s) of outcome(s): Dyadic adjustment scale Dyadic consensus (agreement on time, finances, etc) Dyadic cohesion (common interests, time together) Marital satisfaction (# quarrels, general happiness with each other) Sexual affection Measured during pregnancy, when child 2 months and 12 months | 1) Dyadic cohesion decreased from 2 – 12 months for control women 2) Sexual satisfaction significantly lower at 2 months for control men, returned to same as ART men by 12 months | | | | Comments: Dropout rate higher among controls (34% vs. 27%) Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: - Analysis (multivariate adjustments) and reporting of results: +
Rice, McIntosh, and Halstead, 2005 #9050 | Geographical location: British Columbia Study dates: Jan 1999 – Dec 2002 Size of population: IVF 88 Natural 596 Study type: Cohort | Age: Mean 33–34 Range 21.05 – 44.93 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Matched controls for maternal age, gestational age at time of sampling, serum sampling date Exclusion criteria: If corrected for Insulin-dependent diabetes or ethnicity Multiple gestations, even if >1 sac on early ultrasound | Definition(s) of outcome(s): Down's Syndrome = serum analysis of screen positive 1/385 or greater | 1) Analyte levels in Down's Syndrome false positive rate: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: +/- Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: - Completeness of follow-up: - Analysis (multivariate adjustments) and reporting of results: -
Rice, McIntosh, and Halstead, 2005 #9050 | Geographical location: British Columbia Study dates: Jan 1999 – Dec 2002 Size of population: IVF 88 Natural 596 Study type: Cohort | | Definition(s) of outcome(s): Down's Syndrome = serum analysis of screen positive 1/385 or greater | | screen+ | screen- | Total
Rice, McIntosh, and Halstead, 2005 #9050 | Geographical location: British Columbia Study dates: Jan 1999 – Dec 2002 Size of population: IVF 88 Natural 596 Study type: Cohort | | Definition(s) of outcome(s): Down's Syndrome = serum analysis of screen positive 1/385 or greater | IVF | 15 | 73 | 88
Rice, McIntosh, and Halstead, 2005 #9050 | Geographical location: British Columbia Study dates: Jan 1999 – Dec 2002 Size of population: IVF 88 Natural 596 Study type: Cohort | | Definition(s) of outcome(s): Down's Syndrome = serum analysis of screen positive 1/385 or greater | spontaneous | 81 | 515 | 596
Rice, McIntosh, and Halstead, 2005 #9050 | Geographical location: British Columbia Study dates: Jan 1999 – Dec 2002 Size of population: IVF 88 Natural 596 Study type: Cohort | | Definition(s) of outcome(s): Down's Syndrome = serum analysis of screen positive 1/385 or greater | Total | 96 | 588 | 684
Rice, McIntosh, and Halstead, 2005 #9050 | Geographical location: British Columbia Study dates: Jan 1999 – Dec 2002 Size of population: IVF 88 Natural 596 Study type: Cohort | | Definition(s) of outcome(s): Down's Syndrome = serum analysis of screen positive 1/385 or greater | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.25 | 0.76 | 2.07
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | Age: % < 30: ART: 18.6% (singletons), 21.6% (twins) Spontaneous: 59.7% (singletons), 50.4% (twins) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Norwegian Birth Registry; Exclusion criteria:; - Gestational age < 22 wk; - Birthweight < 500 g; - Mother < 20; - Parity ≥ 5 | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | 1) Placenta previa, ART singletons: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | | PP + | PP - | Total
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | ART + | 89 | 5492 | 5581
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | ART - | 1821 | 825088 | 826909
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | Total | 1910 | 830580 | 832490
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | | Value | Lower 95% CI | Upper 95% CI
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | Rel risk | 7.24 | 5.86 | 8.94
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | Odds ratio after adjustment for maternal age, parity, previous C-section, duration between births, year of birth: 5.6 (95% CI 4.4, 7.0)
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | 2) Placenta previa, ART twins:
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | | PP + | PP - | Total
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | ART + | 16 | 1971 | 1987
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | ART - | 23 | 10884 | 10907
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | Total | 39 | 12855 | 12894
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | | Value | Lower 95% CI | Upper 95% CI
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | Rel risk | 3.82 | 2.02 | 7.21
Romundstad, Romundstad, Sunde, et al., 2006 #55320 | Geographical location: Norway Study dates: 1988-2002 Size of population (no. of patients): 502, 840 pregnancies Study type: Cohort | | Definition(s) of outcome(s): Placenta previa, diagnosed on US at 18 and 32 wk, confirmed at birth | Odds ratio after adjustment for maternal age, parity, previous C-section, duration between births, year of birth: 2.9 (95% CI 1.5, 5.8)
3) In 1349 women with pregnancies after both spontaneous and assisted conception, odds ratio for placenta previa with assisted conception after adjustment for maternal age, parity, and previous C-section: 2.9 (1.4, 6.1)
Rossing, Tang, Flagg, et al., 2004 #12060 | Geographical location: Atlanta, GA, Detroit, MI, Seattle, WA Study dates: 1994 - 1998 Size of population: 378 cases interviewed of 547 eligible, 1,637 controls of 2,228 available Study type: Case-control, in-person interviews, identified subjects through tumor registry | Age: Range: 35–54 Age stratified into 5-yr blocks Race/ethnicity (n [%]): Cases 13.5% black Controls 27.1% black, all else white Diagnoses (n): Endometriosis: 23 Tubal factor: 52 ovarian: 34 Cervical: 7 Endocrine: 27 Uterine: 26 Inclusion criteria: English speaking, white or black women residents of specified cities, 35–54 yrs old when diagnosed with first ovarian cancer, telephone service Exclusion criteria: NR | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | Results stratified by Nulliparous vs. parous | | | | Comments: None Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: - Comparability of cases and controls with respect to potential confounders: + Validated dietary assessment method: n/a Appropriateness of statistical analyses: +
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | 1) Nulliparous, history of infertility:
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | | Ov CA+ | Ov CA- | Total
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | Infertility+ | 42 | 66 | 108
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | Infertility- | 98 | 245 | 343
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | Total | 140 | 311 | 451
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | | Value | Lower 95% CI | Upper 95% CI
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | Odds rat | 1.59 | 1.01 | 2.50
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | 2) Parous, history of infertility:
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | | Ov CA+ | Ov CA- | Total
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | Infertility+ | 101 | 169 | 270
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | Infertility- | 512 | 779 | 1291
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | Total | 613 | 948 | 1561
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | | Value | Lower 95% CI | Upper 95% CI
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | Odds rat | 0.91 | 0.69 | 1.19
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | 3) Nulliparous, use of ovulation-inducing drugs:
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | | Ov CA+ | Ov CA- | Total
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | ovulationinduction+ | 5 | 103 | 108
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | ovulation induction- | 18 | 325 | 343
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | Total | 23 | 428 | 451
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | | Value | Lower 95% CI | Upper 95% CI
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | Odds rat | 0.88 | 0.32 | 2.42
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | 4) Parous, use of ovulation-inducing drugs:
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | | Ov CA+ | Ov CA- | Total
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | ovulation indx+ | 12 | 258 | 270
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | ovulation indx - | 67 | 1224 | 1291
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | Total | 79 | 1482 | 1561
Rossing, Tang, Flagg, et al., 2004 #12060 | | | Definition(s) of outcome(s): History of infertility and use of ovulation inducing drugs on risk of ovarian cancer | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 0.85 | 0.45 | 1.59
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | Geographical location: Ankara, Turkey Study dates: 1999-2003 Size of population (no. of patients): All twins 274 ICSI (12 underwent fetal reduction from triplets to twins) 348 spontaneous conception Study type: Cohort | Age: Mean (SD): ICSI: 31.45 (4.42) Spontaneous: 28.94 (4.37) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins delivered after 24wks Exclusion criteria: Any ovarian stimulation or insemination procedures in control group | Definition(s) of outcome(s): Preterm birth < 37 wk Low birthweight < 2500 g Respiratory distress syndrome Perinatal morbidity and mortality (> 22 wks gestation stillbirth + neonatal death to 7 days of life) | 1) Preterm birth: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | | PTB + | PTB - | Total
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | ICSI | 210 | 64 | 274
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Spontaneous | 223 | 125 | 348
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Total | 433 | 189 | 622
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | | Value | Lower 95% CI | Upper 95% CI
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Rel risk | 1.20 | 1.08 | 1.32
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | 2) Low birthweight:
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | | LBWT + | LBWT - | Total
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | ICSI | 200 | 74 | 274
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Spontaneous | 210 | 138 | 348
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Total | 410 | 212 | 622
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | | Value | Lower 95% CI | Upper 95% CI
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Rel risk | 1.21 | 1.08 | 1.35
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | 3) Gestational diabetes:
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | | GDM + | GDM - | Total
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | ICSI | 22 | 252 | 274
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Spontaneous | 10 | 338 | 348
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Total | 32 | 590 | 622
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | | Value | Lower 95% CI | Upper 95% CI
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Rel risk | 2.79 | 1.35 | 5.80
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | 4) Respiratory distress syndrome:
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | | RDS + | RDS - | Total
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | ICSI | 15 | 259 | 274
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Spontaneous | 5 | 343 | 348
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Total | 20 | 602 | 622
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | | Value | Lower 95% CI | Upper 95% CI
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Rel risk | 3.81 | 1.40 | 10.35
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | 5) Perinatal mortality:
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | | Perinatal mort + | Perinatal mort - | Total
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | ICSI | 22 | 252 | 274
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Spontaneous | 9 | 339 | 348
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Total | 31 | 591 | 622
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | | Value | Lower 95% CI | Upper 95% CI
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Rel risk | 3.10 | 1.45 | 6.63
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | 6) Perinatal morbidity:
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | | Perinatal morbidity+ | Perinatal morbidity- | Total
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | ICSI | 45 | 229 | 274
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Spontaneous | 27 | 321 | 348
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | Total | 72 | 550 | 622
Saygan-Karamursel, Tekam, Aksu, et al., 2006 #55480 | | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 2.12 | 1.35 | 3.32
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | Age: Mean (SD): OI/COH 30.2 (6.7) IVF Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Pregnancy after ART (OI w/COH, IVF, or micromanipulation (ICSI or assisted hatching) Exclusion criteria: NR | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | 1) MZ twinning by method of conception: OI vs IVF: | | | | Comments:; - Micromanipulation grp is heterogeneous in indications as well as procedures.; - Ultrasound may mistakenly characterize zygosity; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for genomic test: n/a Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | | MZ+ | MZ- | Total
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | OI | 2 | 127 | 129
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | IVF | 1 | 138 | 139
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | Total | 3 | 265 | 268
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | | Value | Lower 95% CI | Upper 95% CI
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | Odds rat | 2.17 | 0.19 | 24.26
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | 2) MZ twinning by method of conception: IVF vs IVF w/micromanipulation:
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | | MZ+ | MZ- | Total
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | IVF | 1 | 138 | 139
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | micro | 4 | 459 | 463
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | Total | 5 | 597 | 602
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | | Value | Lower 95% CI | Upper 95% CI
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | Odds rat | 0.83 | 0.09 | 7.50
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | 3) MZ twinning by method of conception: OI vs IVF w/micromanipulation:
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | | MZ+ | MZ- | Total
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | OI | 2 | 127 | 129
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | micro | 4 | 459 | 463
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | Total | 6 | 586 | 592
Schachter, Raziel, Friedler, et al. 2001 #5060 | Geographical location: Tel Aviv, Israel Study dates: 1997 – 99 Size of population: 731 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Monozygotic twinning = chorionicity demonstrated by US up to 9wks | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.81 | 0.33 | 9.98
Schieve, Meikle, Ferre, et al., 2002 #2510 | Geographical location: U.S. national data Study dates: 1996-1997 Size of population: 42,463 infants (18,408 singletons) Study type: Cohort | Age: Range: 20–60 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 7.8% Female factor: 68.1% Male factor: 24.1% Inclusion criteria:; - Infants born in 1996 and 1997; - Conceived with ART; Exclusion criteria:; - Stillbirths (n = 182); - Missing birthweight (n = 3241) | Definition(s) of outcome(s): Low birth weight ≤ 2500 g Very low birthweight < 1500 g | 1) LBWT for ART vs. spontaneous: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Schieve, Meikle, Ferre, et al., 2002 #2510 | Geographical location: U.S. national data Study dates: 1996-1997 Size of population: 42,463 infants (18,408 singletons) Study type: Cohort | | Definition(s) of outcome(s): Low birth weight ≤ 2500 g Very low birthweight < 1500 g | | LBWT + | LBWT - | Total
Schieve, Meikle, Ferre, et al., 2002 #2510 | Geographical location: U.S. national data Study dates: 1996-1997 Size of population: 42,463 infants (18,408 singletons) Study type: Cohort | | Definition(s) of outcome(s): Low birth weight ≤ 2500 g Very low birthweight < 1500 g | ART | 2423 | 15975 | 18398
Schieve, Meikle, Ferre, et al., 2002 #2510 | Geographical location: U.S. national data Study dates: 1996-1997 Size of population: 42,463 infants (18,408 singletons) Study type: Cohort | | Definition(s) of outcome(s): Low birth weight ≤ 2500 g Very low birthweight < 1500 g | Spontaneous | 1339.4 | 17058.6 | 18398
Schieve, Meikle, Ferre, et al., 2002 #2510 | Geographical location: U.S. national data Study dates: 1996-1997 Size of population: 42,463 infants (18,408 singletons) Study type: Cohort | | Definition(s) of outcome(s): Low birth weight ≤ 2500 g Very low birthweight < 1500 g | Total | 3762.4 | 33033.6 | 36796
Schieve, Meikle, Ferre, et al., 2002 #2510 | Geographical location: U.S. national data Study dates: 1996-1997 Size of population: 42,463 infants (18,408 singletons) Study type: Cohort | | Definition(s) of outcome(s): Low birth weight ≤ 2500 g Very low birthweight < 1500 g | | Value | Lower 95% CI | Upper 95% CI
Schieve, Meikle, Ferre, et al., 2002 #2510 | Geographical location: U.S. national data Study dates: 1996-1997 Size of population: 42,463 infants (18,408 singletons) Study type: Cohort | | Definition(s) of outcome(s): Low birth weight ≤ 2500 g Very low birthweight < 1500 g | Rel risk | 1.81 | 1.70 | 1.93
Schieve, Meikle, Ferre, et al., 2002 #2510 | Geographical location: U.S. national data Study dates: 1996-1997 Size of population: 42,463 infants (18,408 singletons) Study type: Cohort | | Definition(s) of outcome(s): Low birth weight ≤ 2500 g Very low birthweight < 1500 g | 2) Very LBWT for ART vs. spontaneous:
Schieve, Meikle, Ferre, et al., 2002 #2510 | Geographical location: U.S. national data Study dates: 1996-1997 Size of population: 42,463 infants (18,408 singletons) Study type: Cohort | | Definition(s) of outcome(s): Low birth weight ≤ 2500 g Very low birthweight < 1500 g | | VLBWT + | VLBWT | Total
Schieve, Meikle, Ferre, et al., 2002 #2510 | Geographical location: U.S. national data Study dates: 1996-1997 Size of population: 42,463 infants (18,408 singletons) Study type: Cohort | | Definition(s) of outcome(s): Low birth weight ≤ 2500 g Very low birthweight < 1500 g | ART | 480 | 17918 | 18398
Schieve, Meikle, Ferre, et al., 2002 #2510 | Geographical location: U.S. national data Study dates: 1996-1997 Size of population: 42,463 infants (18,408 singletons) Study type: Cohort | | Definition(s) of outcome(s): Low birth weight ≤ 2500 g Very low birthweight < 1500 g | Spontaneous | 263.4 | 18134.6 | 18398
Schieve, Meikle, Ferre, et al., 2002 #2510 | Geographical location: U.S. national data Study dates: 1996-1997 Size of population: 42,463 infants (18,408 singletons) Study type: Cohort | | Definition(s) of outcome(s): Low birth weight ≤ 2500 g Very low birthweight < 1500 g | Total | 743.4 | 36052.6 | 36796
Schieve, Meikle, Ferre, et al., 2002 #2510 | Geographical location: U.S. national data Study dates: 1996-1997 Size of population: 42,463 infants (18,408 singletons) Study type: Cohort | | Definition(s) of outcome(s): Low birth weight ≤ 2500 g Very low birthweight < 1500 g | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.82 | 1.57 | 2.11
Schieve, Tatham, Peterson, et al., 2003 #16730 | Geographical location: United States Study dates: 1996-98 Size of population (no. of patients): N = 62,228 ART pregnancies Study type: Cohort | Age: 20–20 n = 8143 30–34 n = 22,190 35–37 n = 14,128 38–40 n = 9948 41–43 n = 4899 44–47 n = 2372 48–55 n = 548 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 4886, 7.9% Endometriosis: 8531, 13.7% Male factor: 15,350, 24.7% Tubal factor: 15,450, 24.8% PCOS:9716, 15.6% Other (specify): Uterine factor 1201, 1.9% Other causes 7089, 11.4% Inclusion criteria: Clinical pregnancy Exclusion criteria:; - Ectopic pregnancy; - Incomplete data - Stillbirths; - Induced abortions | Definition(s) of outcome(s): Spontaneous abortion = loss of entire pregnancy | 1) Spontaneous abortion, singletons vs. triplets (derived from total number of pregnancies and reported rates by plurality): | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: - Completeness of follow-up: - Analysis (multivariate adjustments) and reporting of results: +
Schieve, Tatham, Peterson, et al., 2003 #16730 | Geographical location: United States Study dates: 1996-98 Size of population (no. of patients): N = 62,228 ART pregnancies Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion = loss of entire pregnancy | | SAb + | SAb - | Total
Schieve, Tatham, Peterson, et al., 2003 #16730 | Geographical location: United States Study dates: 1996-98 Size of population (no. of patients): N = 62,228 ART pregnancies Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion = loss of entire pregnancy | Twins | 1379 | 17012 | 18391
Schieve, Tatham, Peterson, et al., 2003 #16730 | Geographical location: United States Study dates: 1996-98 Size of population (no. of patients): N = 62,228 ART pregnancies Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion = loss of entire pregnancy | Singleton | 7118 | 27865 | 34983
Schieve, Tatham, Peterson, et al., 2003 #16730 | Geographical location: United States Study dates: 1996-98 Size of population (no. of patients): N = 62,228 ART pregnancies Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion = loss of entire pregnancy | Total | 8497 | 44877 | 53374
Schieve, Tatham, Peterson, et al., 2003 #16730 | Geographical location: United States Study dates: 1996-98 Size of population (no. of patients): N = 62,228 ART pregnancies Study type: Cohort | | Definition(s) of outcome(s): Spontaneous abortion = loss of entire pregnancy | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.37 | 0.35 | 0.39
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: LIveborn, <1500 grams Exclusion criteria:; - < 24 weeks; - Liveborns from pregnancies with selective reduction, stillbirth, or elective termination; - Pregnancies from non-ART infertility treatment (e.g., ovulation induction); - Greater than 3 infants | Definition(s) of outcome(s): Mortality—death prior to discharge from hospital Necrotizing enterocolitis (NEC) Intraventricular hemorrhage (IVH) Respiratory distress syndrome (RDS) Bronchopulmonary dysplasia (BPD) Patent ductus arteriosis (PDA) Congenital malformations | 1) Adjusted odds ratios, ART vs spontaneous singletons (adjusted for maternal age, gestational age, birth weight, SGA, ethnicity, antenatal steroid therapy, maternal hypertension, delivery mode, and resuscitation): | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes:+ Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | Outcome | OR | 95%CI
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | Mortality | 1.06 | 0.72,1.53
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | RDS | 0.87 | 0.65,1.17
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | PDA | 1.04 | 0.76,1.41
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | NEC | 0.75 | 0.41,1.27
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | IVH | 1.35 | 0.82,2.13
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | BPD | 0.91 | 0.58,1.39
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | Malformation | 1.47 | 0.96,2.19
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | 2) Adjusted odds ratios, ART vs spontaneous singletons (adjusted for maternal age, gestational age, birth weight, SGA, ethnicity, antenatal steroid therapy, maternal hypertension, delivery mode, and resuscitation):
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | Outcome | OR | 95%CI
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | Mortality | 0.71 | 0.51,1.01
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | RDS | 0.88 | 0.64,1.22
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | PDA | 1.01 | 0.77,1.32
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | NEC | 0.95 | 0.61,1.49
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | IVH | 0.78 | 0.53,1.14
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | BPD | 0.76 | 0.50,1.16
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | Malformation | 0.84 | 0.52,1.37
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | 3) Adjusted odds ratios, ART vs spontaneous triplets (adjusted for maternal age, gestational age, birth weight, SGA, ethnicity, antenatal steroid therapy, maternal hypertension, delivery mode, and resuscitation):
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | Outcome | OR | 95%CI
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | Mortality | 0.73 | 0.25,2.15
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | RDS | 1.58 | 0.53,1.67
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | PDA | 0.74 | 0.32,1.71
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | NEC | 0.76 | 0.17,3.34
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | IVH | 1.78 | 0.60,5.30
Schimmel, Hammerman, Lusky, et al., 2006 #55510 | Geographical location: Israel Study dates: 1995-2002 Size of population (no. of patients): 8181 Study type: Cohort | | | BPD | 0.97 | 0.33,2.86
Malformation | 4.31 | 0.63,29.4
Sheard, Cox, Oates, et al., 2007 #72500 | Geographical location: Nottingham, UK Study dates: NR Size of population (no. of patients): 175 Study type: Cohort | Age: Median: Singletons 33 Multiples 34 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known to have successfully conceived following treatment for infertility at a research and treatment unit in a UK hospital; - At least 18 weeks pregnant; - Resident in the UK and English speaking; - First time mothers.; Exclusion criteria:; - Unable to be contacted at time point; - Neonatal death; - Not available for interview | Definition(s) of outcome(s): Depression at 6 weeks postpartum measured by Edinburgh Postnatal Depression Scale | 1) Depression (EPDS > 12), multiples vs. singletons: | | | | Comments: Only 38% acceptance rate Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Sheard, Cox, Oates, et al., 2007 #72500 | Geographical location: Nottingham, UK Study dates: NR Size of population (no. of patients): 175 Study type: Cohort | | Definition(s) of outcome(s): Depression at 6 weeks postpartum measured by Edinburgh Postnatal Depression Scale | | EPDS | EPDS
Sheard, Cox, Oates, et al., 2007 #72500 | Geographical location: Nottingham, UK Study dates: NR Size of population (no. of patients): 175 Study type: Cohort | | Definition(s) of outcome(s): Depression at 6 weeks postpartum measured by Edinburgh Postnatal Depression Scale | | >12 | ≤12 | Total
Sheard, Cox, Oates, et al., 2007 #72500 | Geographical location: Nottingham, UK Study dates: NR Size of population (no. of patients): 175 Study type: Cohort | | Definition(s) of outcome(s): Depression at 6 weeks postpartum measured by Edinburgh Postnatal Depression Scale | Multiples | 7 | 39 | 46
Sheard, Cox, Oates, et al., 2007 #72500 | Geographical location: Nottingham, UK Study dates: NR Size of population (no. of patients): 175 Study type: Cohort | | Definition(s) of outcome(s): Depression at 6 weeks postpartum measured by Edinburgh Postnatal Depression Scale | Singletons | 6 | 99 | 105
Sheard, Cox, Oates, et al., 2007 #72500 | Geographical location: Nottingham, UK Study dates: NR Size of population (no. of patients): 175 Study type: Cohort | | Definition(s) of outcome(s): Depression at 6 weeks postpartum measured by Edinburgh Postnatal Depression Scale | Total | 13 | 138 | 151
Sheard, Cox, Oates, et al., 2007 #72500 | Geographical location: Nottingham, UK Study dates: NR Size of population (no. of patients): 175 Study type: Cohort | | Definition(s) of outcome(s): Depression at 6 weeks postpartum measured by Edinburgh Postnatal Depression Scale | | Value | Lower 95% CI | Upper 95% CI
Sheard, Cox, Oates, et al., 2007 #72500 | Geographical location: Nottingham, UK Study dates: NR Size of population (no. of patients): 175 Study type: Cohort | | Definition(s) of outcome(s): Depression at 6 weeks postpartum measured by Edinburgh Postnatal Depression Scale | Rel risk | 2.66 | 0.95 | 7.49
2) Adjusted for maternal age, cesarean, weeks postpartum, and “unsettled baby” score, risk for EPDS > 12 for multiples 3.43 (1.01, 11.6)
Sheiner, Shoham-Vardi, Hershkovitz, et al., 2001 #3790 | Geographical location: Beer Sheva, Israel Study dates: 1990-98 Size of population: Infertility treatment n = 35 Spontaneous conception n = 80 Study type: Cohort (retrospective) | Age: Mean (SD): Infertility: 43.9 (9.3) Spontaneous: 43.9 (5.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All singleton births to nulliparous women > 40 yo during study period Exclusion criteria: NR | Definition(s) of outcome(s): Cesarean section | 1) Infertility treatment as risk factor for C/S: | | | | Comments:; - Authors state this institution is regional teaching hospital at which virtually all births to women in southern Israel take place, so nonselective; - Infertility grp included IVF & OI pts; - Infertility grp gave birth to more infants with BW < 2500 g and > 4000 g; - Comparable rates of PTD, medical problems, induction of labor, meconium-stained fluid, congenital malformations, placenta previa, abruption, malpresentation; - No mention of maternal obesity; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: + Use of validated method for genomic test: n/a Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Sheiner, Shoham-Vardi, Hershkovitz, et al., 2001 #3790 | Geographical location: Beer Sheva, Israel Study dates: 1990-98 Size of population: Infertility treatment n = 35 Spontaneous conception n = 80 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Cesarean section | | C/S + | C/S - | Total
Sheiner, Shoham-Vardi, Hershkovitz, et al., 2001 #3790 | Geographical location: Beer Sheva, Israel Study dates: 1990-98 Size of population: Infertility treatment n = 35 Spontaneous conception n = 80 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Cesarean section | Infert | 25 | 10 | 35
Sheiner, Shoham-Vardi, Hershkovitz, et al., 2001 #3790 | Geographical location: Beer Sheva, Israel Study dates: 1990-98 Size of population: Infertility treatment n = 35 Spontaneous conception n = 80 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Cesarean section | Spont | 33 | 47 | 80
Sheiner, Shoham-Vardi, Hershkovitz, et al., 2001 #3790 | Geographical location: Beer Sheva, Israel Study dates: 1990-98 Size of population: Infertility treatment n = 35 Spontaneous conception n = 80 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Cesarean section | Total | 58 | 57 | 115
Sheiner, Shoham-Vardi, Hershkovitz, et al., 2001 #3790 | Geographical location: Beer Sheva, Israel Study dates: 1990-98 Size of population: Infertility treatment n = 35 Spontaneous conception n = 80 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Cesarean section | | Value | Lower 95% CI | Upper 95% CI
Sheiner, Shoham-Vardi, Hershkovitz, et al., 2001 #3790 | Geographical location: Beer Sheva, Israel Study dates: 1990-98 Size of population: Infertility treatment n = 35 Spontaneous conception n = 80 Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Cesarean section | Odds rat | 3.56 | 1.51 | 8.40
When adjusted for malpresentation, arrest of 1^st^/2^nd^ stage, NRFHR, abruption, previa, cord prolapse, PROM, hydramnios, oligo, GDMA2, failed induction, severe PIH, IUGR - OR remained significantly elevated.
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | Age: Spontaneous 29.9 (5.7) Ovulation indx 32.6 (5.1) IVF 34.5 (5.2) Race/ethnicity (n [%]): Spont / ov indx / IVF: African Am 5.3/ 1.6/ 2.7 Hispanic 23.3/ 4.5/ 4.5 White 66.6/ 88.6/ 86.3 Other 4.9/ 5.2/ 6.5 Diagnoses (n [%]): NR Inclusion criteria:; - Singleton pregnancy; - Enrolled 10–13.9 wk into FASTER trial for noninvasive Downs syndrome screening; Exclusion criteria: Pts who elected pregnancy termination | Definition(s) of outcome(s): FGR < 10^th^ percentile LBWT < 2500 g Preeclampsia (gestational HTN + proteinuria) PTB < 37 wk PPROM < 37 wk Placental abruption - premature separation of placenta Placenta previa GDM Cesarean delivery Fetal aneuploidy Congenital anomalies - major or minor confirmed at birth | 1) PTB for ovulation indx vs. spontaneous: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | PTB + | PTB - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Ov indx | 8 | 114 | 122
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 1783 | 32503 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 1791 | 32617 | 34408
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 1.26 | 0.64 | 2.47
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 2) PTB for IVF vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | PTB + | PTB - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | IVF | 38 | 516 | 554
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 1783 | 32503 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 1821 | 33019 | 34840
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 1.32 | 0.97 | 1.80
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 3) FGR for ovulation indx vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | FGR + | FGR - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Ov indx | 3 | 119 | 122
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 377 | 33909 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 380 | 34028 | 34408
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 2.24 | 0.73 | 6.87
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 4) FGR for IVF vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | FGR + | FGR - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | IVF | 5 | 549 | 554
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 377 | 33909 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 382 | 34458 | 34840
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 0.82 | 0.34 | 1.98
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 5) LBWT for ov indx vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | LBWT + | LBWT - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Ov indx | 9 | 113 | 122
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 1749 | 32537 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 1758 | 32650 | 34408
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 1.45 | 0.77 | 2.72
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 6) LBWT for IVF vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | LBWT + | LBWT - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | IVF | 33 | 521 | 554
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 1749 | 32537 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 1782 | 33058 | 34840
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 1.17 | 0.84 | 1.63
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 7) Preeclampsia for ov indx vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Preecl + | Preecl - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Ov indx | 4 | 118 | 122
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 823 | 33463 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 827 | 33581 | 34408
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 1.37 | 0.52 | 3.59
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 8) Preeclampsia for IVF vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Preecl + | Preecl - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | IVF | 26 | 528 | 554
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 823 | 33463 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 849 | 33991 | 34840
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 1.96 | 1.34 | 2.86
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 9) Gestational diabetes for ov indx vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | GDM + | GDM - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Ov indx | 7 | 115 | 122
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 1166 | 33120 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 1173 | 33235 | 34408
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 1.69 | 0.82 | 3.47
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 10) Gestational diabetes for IVF vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | GDM + | GDM - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | IVF | 15 | 539 | 554
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 1166 | 33120 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 1181 | 33659 | 34840
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 0.80 | 0.48 | 1.32
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 11) Cesarean delivery for ov indx vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Ces + | Ces - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Ov indx | 32 | 90 | 122
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 8091 | 26195 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 8123 | 26285 | 34408
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 1.11 | 0.82 | 1.50
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 12) Cesarean delivery for IVF vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Ces + | Ces - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | IVF | 261 | 293 | 554
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 8091 | 26195 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 8352 | 26488 | 34840
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 2.00 | 1.82 | 2.18
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 13) PPROM for ov indx vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | PPROM + | PPROM - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Ov indx | 2 | 120 | 122
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 549 | 33737 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 551 | 33857 | 34408
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 1.02 | 0.26 | 4.06
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 14) PPROM for IVF vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | PPROM + | PPROM - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | IVF | 12 | 542 | 554
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 549 | 33737 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 561 | 34279 | 34840
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 1.35 | 0.77 | 2.38
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 15) Placental abruption for ov indx vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Abrupt + | Abrupt - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Ov indx | 2 | 120 | 122
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 240 | 34046 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 242 | 34166 | 34408
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 2.34 | 0.59 | 9.31
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 16) Placental abruption for IVF vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Abrupt + | Abrupt - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | IVF | 12 | 542 | 554
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 240 | 34046 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 252 | 34588 | 34840
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 3.09 | 1.74 | 5.49
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 17) Placenta previa for ov indx vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Previa + | Previa - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Ov indx | 1 | 121 | 122
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 206 | 34080 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 207 | 34201 | 34408
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 1.36 | 0.19 | 9.65
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 18) Placenta previa for IVF vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Previa + | Previa - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | IVF | 12 | 542 | 554
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 206 | 34080 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 218 | 34622 | 34840
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 3.61 | 2.03 | 6.41
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 19) Aneuploidy for ov indx vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Aneupl + | Aneupl - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Ov indx | 0.5 | 121.5 | 122
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 137 | 34149 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 137.5 | 34270.5 | 34408
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 1.03 | 0.06 | 16.39
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 20) Aneuploidy for IVF vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Aneupl + | Aneupl - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | IVF | 2 | 552 | 554
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 137 | 34149 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 139 | 34701 | 34840
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 0.90 | 0.22 | 3.64
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 21) Congenital anomalies for ov indx vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Anomaly + | Anomaly - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Ov indx | 3 | 119 | 122
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 651 | 33635 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 654 | 33754 | 34408
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Rel risk | 1.30 | 0.42 | 3.97
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | 22) Congenital anomalies for IVF vs. spontaneous:
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Anomaly + | Anomaly - | Total
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | IVF | 19 | 535 | 554
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Spont | 651 | 33635 | 34286
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | Total | 670 | 34170 | 34840
Shevell, Malone, Vidaver, et al., 2005 #39410 | Geographical location: U.S., multicenter Study dates: 1999-2002 Size of population: 36,062 pregnancies-34,286 spontaneous, 1222 ovulation induction, 554 IVF Study type: Cohort | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.81 | 1.15 | 2.83
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | Age (mean [SD]): 35 (4.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): All had male factor but female factors not described Inclusion criteria: IVF patients with documented pregnancy by u/s Exclusion criteria: NR | Definition(s) of outcome(s): NR | 1) Monozygotic twin rate in assisted hatching vs. routine IVF: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): not stated Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | | MZ twins+ | MZ twins- | Total
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | AH | 9 | 636 | 645
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | IVF | 3 | 210 | 213
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | Total | 12 | 846 | 858
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | | Value | Lower 95% CI | Upper 95% CI
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | Rel risk | 0.99 | 0.27 | 3.63
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | 2) MZ twin rate in ICSI vs. routine IVF:
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | | MZ twins+ | MZ twins- | Total
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | ICSI | 2 | 175 | 177
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | IVF | 3 | 210 | 213
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | Total | 5 | 385 | 390
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | | Value | Lower 95% CI | Upper 95% CI
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | Rel risk | 0.80 | 0.14 | 4.75
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | 3) MZ twin rate for assisted hatching + icsi vs. routine IVF:
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | | MZ twins+ | MZ twins- | Total
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | AH+ICSI | 9 | 868 | 877
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | IVF | 3 | 210 | 213
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | Total | 12 | 1078 | 1090
Sillis, Moomjy, Zaninovic, et al. 2000 #8190 | Geographical location: New York, New York Study dates: Jan 1995 – March 1998 Size of population: 1,911 patients with 23 monozygotic twins Study type: Cohort | | Definition(s) of outcome(s): NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.73 | 0.20 | 2.67
Soares, Troncoso, Bosch, et al., 2005 #8920 | Geographical location: Valencia, Spain Study dates: 1999-2003 Size of population (no. of patients): 106 singleton births Number of cycles analyzed: 3089 oocyte donation cycles Number of cycles per patient: # oocyte recipients not reported Study type: Cohort | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | 1) PTB by age of oocyte recipient: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: - Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: - Completeness of follow-up: - Analysis (multivariate adjustments) and reporting of results: +
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | | PTB + | PTB - | Total
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | ≥ 45 yo | 8 | 4 | 12
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | < 45 yo | 18 | 76 | 94
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | Total | 26 | 80 | 106
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | | Value | Lower 95% CI | Upper 95% CI
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | Rel risk | 3.48 | 1.96 | 6.20
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | 2) Hypertension by age of oocyte recipient:
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | | HTN + | HTN - | Total
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | ≥ 45 yo | 4 | 8 | 12
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | < 45 yo | 10 | 84 | 94
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | Total | 14 | 92 | 106
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | | Value | Lower 95% CI | Upper 95% CI
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | Rel risk | 3.13 | 1.16 | 8.45
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | 3) GDM by age of oocyte recipient:
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | | GDM + | GDM - | Total
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | ≥ 45 yo | 3 | 9 | 12
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | < 45 yo | 13 | 81 | 94
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | Total | 16 | 90 | 106
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | | Value | Lower 95% CI | Upper 95% CI
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | Rel risk | 1.81 | 0.60 | 5.44
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | 4) PPROM by age of oocyte recipient:
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | | PPROM+ | PPROM - | Total
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | ≥ 45 yo | 3 | 9 | 12
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | < 45 yo | 4 | 90 | 94
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | Total | 7 | 99 | 106
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | | Value | Lower 95% CI | Upper 95% CI
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | Rel risk | 5.88 | 1.49 | 23.15
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | 5) Cesarean delivery by age of oocyte recipient:
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | | C/S + | C/S - | Total
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | ≥ 45 yo | 12 | 0 | 12
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | < 45 yo | 78 | 16 | 94
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | Total | 90 | 16 | 106
Soares, Troncoso, Bosch, et al., 2005 #8920 | | Age: Oocyte recipients 38.9 (5.2) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Oocyte recipient IVF Exclusion criteria: Severe male factor | Definition(s) of outcome(s): PTB not defined Hypertension GDM PPROM Cesarean delivery | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.16 | 1.01 | 1.34
Spandorfer, Davis, Barmat, et al., 2004 #13220 | Geographical location: New York, NY Study dates: 1991-96 Size of population: 2014 IVF pregnancies 233 spontaneous loss after cardiac activity 1781 deliveries Study type: Retrospective cohort | Age: Mean (SD): SAb: 37.3 (3.8) Normal: 35.1 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: IVF with fresh embryo transfer Exclusion criteria: Selective reduction Elective termination due to chromosome abnl or congenital malformation | Definition(s) of outcome(s): Spontaneous abortion = fetal loss after documented fetal cardiac activity by 7-wk US | Overall 11.6% SAb incidence | | | | Comments: Report aneuploidy/chromosome results from 71/233 SAbs, difficult to interpret results due to significant amount of missing data Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Spandorfer, Davis, Barmat, et al., 2004 #13220 | Geographical location: New York, NY Study dates: 1991-96 Size of population: 2014 IVF pregnancies 233 spontaneous loss after cardiac activity 1781 deliveries Study type: Retrospective cohort | | Definition(s) of outcome(s): Spontaneous abortion = fetal loss after documented fetal cardiac activity by 7-wk US | 1) SAb risk by age:
Spandorfer, Davis, Barmat, et al., 2004 #13220 | Geographical location: New York, NY Study dates: 1991-96 Size of population: 2014 IVF pregnancies 233 spontaneous loss after cardiac activity 1781 deliveries Study type: Retrospective cohort | | Definition(s) of outcome(s): Spontaneous abortion = fetal loss after documented fetal cardiac activity by 7-wk US | | SAb + | SAb - | Total
Spandorfer, Davis, Barmat, et al., 2004 #13220 | Geographical location: New York, NY Study dates: 1991-96 Size of population: 2014 IVF pregnancies 233 spontaneous loss after cardiac activity 1781 deliveries Study type: Retrospective cohort | | Definition(s) of outcome(s): Spontaneous abortion = fetal loss after documented fetal cardiac activity by 7-wk US | Age ≥ 35 | 171 | 940 | 1111
Spandorfer, Davis, Barmat, et al., 2004 #13220 | Geographical location: New York, NY Study dates: 1991-96 Size of population: 2014 IVF pregnancies 233 spontaneous loss after cardiac activity 1781 deliveries Study type: Retrospective cohort | | Definition(s) of outcome(s): Spontaneous abortion = fetal loss after documented fetal cardiac activity by 7-wk US | Age < 35 | 62 | 841 | 903
Spandorfer, Davis, Barmat, et al., 2004 #13220 | Geographical location: New York, NY Study dates: 1991-96 Size of population: 2014 IVF pregnancies 233 spontaneous loss after cardiac activity 1781 deliveries Study type: Retrospective cohort | | Definition(s) of outcome(s): Spontaneous abortion = fetal loss after documented fetal cardiac activity by 7-wk US | Total | 233 | 1781 | 2014
Spandorfer, Davis, Barmat, et al., 2004 #13220 | Geographical location: New York, NY Study dates: 1991-96 Size of population: 2014 IVF pregnancies 233 spontaneous loss after cardiac activity 1781 deliveries Study type: Retrospective cohort | | Definition(s) of outcome(s): Spontaneous abortion = fetal loss after documented fetal cardiac activity by 7-wk US | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 2.24 | 1.70 | 2.96
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: 2 population based controls per IVF case, matched for sex, yr of birth & hospital 18 mos or older at time of f/u in 1997 Exclusion criteria: NR | Definition(s) of outcome(s): NR | 1) Treatment at childhood disability center for IVF vs. spontaneous singletons: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining clinical outcomes: +/- Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | | Treat + | Treat - | Total
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | IVF | 45 | 3183 | 3228
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | spontaneous | 115 | 10955 | 11070
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | Total | 160 | 14138 | 14298
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | | Value | Lower 95% CI | Upper 95% CI
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | Rel risk | 1.34 | 0.95 | 1.89
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | 2) Treatment at childhood disability center for IVF vs. spontaneous all plurality:
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | | Treat + | Treat - | Total
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | IVF | 101 | 5579 | 5680
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | spontaneous | 119 | 11241 | 11360
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | Total | 220 | 16820 | 17040
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | | Value | Lower 95% CI | Upper 95% CI
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | Rel risk | 1.70 | 1.30 | 2.21
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | 3) Cerebral palsy for IVF vs. spontaneous singletons:
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | | CP+ | CP- | Total
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | IVF | 12 | 3216 | 3228
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | spontaneous | 15 | 11055 | 11070
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | Total | 27 | 14271 | 14298
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | | Value | Lower 95% CI | Upper 95% CI
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | Rel risk | 2.74 | 1.29 | 5.86
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | 4) Cerebral palsy for IVF vs. spontaneous twins:
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | | CP+ | CP- | Total
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | IVF | 15 | 2045 | 2060
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | spontaneous | 28 | 4092 | 4120
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | Total | 43 | 6137 | 6180
Stromberg, Dahlquist, Ericson, et al., 2002 #2700 | Geographical location: Sweden Study dates: 1982 - 1995 Size of population: All plurality IVF 5,680 Spontaneous 11,360 Twins only IVF 2,060 Spontaneous 4,120 Study type: Cohort | | Definition(s) of outcome(s): NR | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.07 | 0.57 | 2.00
Sun, Verstergaard, Christensen, et al., 2007 #56000 | Geographical location: Denmark Study dates: Oct 1997–June 2003 Size of population (no. of patients): 83,194 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Singleton pregnancy; - Enrolled in Danish National Birth Cohort Study; Exclusion criteria:; - Incomplete data on time to pregnancy (n=3539); - Infertility treatment, but not for index pregnancy (n=76) | Definition(s) of outcome(s): Epilepsy—ICD-10 coding from Danish Hospital Registry Febrile seizures—ICD-10 coding, event between 3 months and 5 years, no history of epilepsy prior to event | 1) Epilepsy: | | | | Comments: Time to pregnancy, infertility treatment self-reported (IVF validated with national registry) Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Sun, Verstergaard, Christensen, et al., 2007 #56000 | Geographical location: Denmark Study dates: Oct 1997–June 2003 Size of population (no. of patients): 83,194 Study type: Cohort | | Definition(s) of outcome(s): Epilepsy—ICD-10 coding from Danish Hospital Registry Febrile seizures—ICD-10 coding, event between 3 months and 5 years, no history of epilepsy prior to event
Sun, Verstergaard, Christensen, et al., 2007 #56000 | Geographical location: Denmark Study dates: Oct 1997–June 2003 Size of population (no. of patients): 83,194 Study type: Cohort | | Definition(s) of outcome(s): Epilepsy—ICD-10 coding from Danish Hospital Registry Febrile seizures—ICD-10 coding, event between 3 months and 5 years, no history of epilepsy prior to event | Group | Adjusted incidence rate ratio* | 95% CI
Sun, Verstergaard, Christensen, et al., 2007 #56000 | Geographical location: Denmark Study dates: Oct 1997–June 2003 Size of population (no. of patients): 83,194 Study type: Cohort | | Definition(s) of outcome(s): Epilepsy—ICD-10 coding from Danish Hospital Registry Febrile seizures—ICD-10 coding, event between 3 months and 5 years, no history of epilepsy prior to event | Conceived 1–5 months | 1.00 (ref)
Sun, Verstergaard, Christensen, et al., 2007 #56000 | Geographical location: Denmark Study dates: Oct 1997–June 2003 Size of population (no. of patients): 83,194 Study type: Cohort | | Definition(s) of outcome(s): Epilepsy—ICD-10 coding from Danish Hospital Registry Febrile seizures—ICD-10 coding, event between 3 months and 5 years, no history of epilepsy prior to event | Untreated subfertility | 1.38 | 1.00,1.89
Sun, Verstergaard, Christensen, et al., 2007 #56000 | Geographical location: Denmark Study dates: Oct 1997–June 2003 Size of population (no. of patients): 83,194 Study type: Cohort | | Definition(s) of outcome(s): Epilepsy—ICD-10 coding from Danish Hospital Registry Febrile seizures—ICD-10 coding, event between 3 months and 5 years, no history of epilepsy prior to event | IVF/ICSI | 1.83 | 1.09,3.06
Sun, Verstergaard, Christensen, et al., 2007 #56000 | Geographical location: Denmark Study dates: Oct 1997–June 2003 Size of population (no. of patients): 83,194 Study type: Cohort | | Definition(s) of outcome(s): Epilepsy—ICD-10 coding from Danish Hospital Registry Febrile seizures—ICD-10 coding, event between 3 months and 5 years, no history of epilepsy prior to event | IUI/hormone | 1.73 | 1.06,2.71
Sun, Verstergaard, Christensen, et al., 2007 #56000 | Geographical location: Denmark Study dates: Oct 1997–June 2003 Size of population (no. of patients): 83,194 Study type: Cohort | | Definition(s) of outcome(s): Epilepsy—ICD-10 coding from Danish Hospital Registry Febrile seizures—ICD-10 coding, event between 3 months and 5 years, no history of epilepsy prior to event | *Adjusted for maternal age, social status, BMI, smoking, maternal and paternal history of epilepsy, year of birth
Sun, Verstergaard, Christensen, et al., 2007 #56000 | Geographical location: Denmark Study dates: Oct 1997–June 2003 Size of population (no. of patients): 83,194 Study type: Cohort | | Definition(s) of outcome(s): Epilepsy—ICD-10 coding from Danish Hospital Registry Febrile seizures—ICD-10 coding, event between 3 months and 5 years, no history of epilepsy prior to event | 2) Febrile seizures:
Sun, Verstergaard, Christensen, et al., 2007 #56000 | Geographical location: Denmark Study dates: Oct 1997–June 2003 Size of population (no. of patients): 83,194 Study type: Cohort | | Definition(s) of outcome(s): Epilepsy—ICD-10 coding from Danish Hospital Registry Febrile seizures—ICD-10 coding, event between 3 months and 5 years, no history of epilepsy prior to event | Group | Adjusted incidence rate ratio* | 95% CI
Sun, Verstergaard, Christensen, et al., 2007 #56000 | Geographical location: Denmark Study dates: Oct 1997–June 2003 Size of population (no. of patients): 83,194 Study type: Cohort | | Definition(s) of outcome(s): Epilepsy—ICD-10 coding from Danish Hospital Registry Febrile seizures—ICD-10 coding, event between 3 months and 5 years, no history of epilepsy prior to event | Conceived 1–5 months | 1.00 (ref)
Sun, Verstergaard, Christensen, et al., 2007 #56000 | Geographical location: Denmark Study dates: Oct 1997–June 2003 Size of population (no. of patients): 83,194 Study type: Cohort | | Definition(s) of outcome(s): Epilepsy—ICD-10 coding from Danish Hospital Registry Febrile seizures—ICD-10 coding, event between 3 months and 5 years, no history of epilepsy prior to event | Untreated subfertility | 1.06 | 0.93,1.22
Sun, Verstergaard, Christensen, et al., 2007 #56000 | Geographical location: Denmark Study dates: Oct 1997–June 2003 Size of population (no. of patients): 83,194 Study type: Cohort | | Definition(s) of outcome(s): Epilepsy—ICD-10 coding from Danish Hospital Registry Febrile seizures—ICD-10 coding, event between 3 months and 5 years, no history of epilepsy prior to event | IVF/ICSI | 1.01 | 0.78,1.30
IUI/hormone | 1.37 | 1.14,1.66
*Adjusted for maternal age, social status, BMI, smoking, maternal and paternal history of epilepsy, year of birth
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | Age: ICSI 33.56 (3.93) Natural 30.28 (3.95) Race/ethnicity (n [%]): NR Diagnoses (n [%]): All conceived through ICSI, no further info given Inclusion criteria: Singletons only Controls matched for age, sex, maternal education, social class, geographic region Exclusion criteria: NR | Definition(s) of outcome(s): PTB < 37wks C-section | 1) PTB for IVF vs. spontaneous: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): Large sample size: Adequate description of the cohort: Use of validated method for genomic test: Use of validated method for ascertaining clinical outcomes: Adequate follow-up period: Completeness of follow-up: Analysis (multivariate adjustments) and reporting of results:
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | | Definition(s) of outcome(s): PTB < 37wks C-section | | ptb+ | ptb- | Total
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | | Definition(s) of outcome(s): PTB < 37wks C-section | IVF | 18 | 190 | 208
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | | Definition(s) of outcome(s): PTB < 37wks C-section | spontaneous | 14 | 207 | 221
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | | Definition(s) of outcome(s): PTB < 37wks C-section | Total | 32 | 397 | 429
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | | Definition(s) of outcome(s): PTB < 37wks C-section | | Value | Lower 95% CI | Upper 95% CI
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | | Definition(s) of outcome(s): PTB < 37wks C-section | Rel risk | 1.37 | 0.70 | 2.68
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | | Definition(s) of outcome(s): PTB < 37wks C-section | 2) C-section for IVF vs. spontaneous:
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | | Definition(s) of outcome(s): PTB < 37wks C-section | | C/S+ | C/S- | Total
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | | Definition(s) of outcome(s): PTB < 37wks C-section | IVF | 73 | 135 | 208
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | | Definition(s) of outcome(s): PTB < 37wks C-section | spontaneous | 53 | 168 | 221
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | | Definition(s) of outcome(s): PTB < 37wks C-section | Total | 126 | 303 | 429
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | | Definition(s) of outcome(s): PTB < 37wks C-section | | Value | Lower 95% CI | Upper 95% CI
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | | Definition(s) of outcome(s): PTB < 37wks C-section | Rel risk | 1.46 | 1.09 | 1.97
Sutcliffe, Taylor, Saunders, et al., 2001 #4740 | Geographical location: United Kingdom Study dates: Jan 1997–Jan 1999 Size of population: 208 children born after ICSI 221 naturally conceived Study type: Cohort | | Definition(s) of outcome(s): PTB < 37wks C-section | 3) Neurodevelopmental scoring on Griffith's scale of mental development
IVF 98.08 (10.93) vs. natural 98.69 (9.99)
Sydsjo, Wadsby, Kjellberg, et al., 2002 #450 | Geographical location: Linkoping, Sweden Study dates: Jan 1996–Dec 1997 Size of population: 108 Study Group 108 Controls Study type: Cohort | Age: Study Population Mean (SD): 31.8 ± 3.3 (women) 33.1 ± 3.3 (men) Range: 24–39 (women) 25–40 (men) Controls Mean (SD): Women = study grp 32.3 ± 5.8 (men) Range: Women = study grp 24–50 (men) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Study population - all couples pregnant through IVF at Linkoping University Hospital who agreed to participate and who did not have children Control population - participants in ongoing prospective longitudinal study at Linkoping and were pregnant for the first time matched by maternal age to study group Exclusion criteria:; - Previous pregnancy; - Refusal to participate | Definition(s) of outcome(s): ENRICH marital inventory providing scores of each partner's evaluation of relationship in 10 categories (measured during pregnancy and postpartum):; 1 Personality Issues; 2 Communication; 3 Conflict resolution; 4 Financial management; 5 Leisure activities; 6 Sexual relationship; 7 Children and parenting; 8 Family and friends; 9 Equalitarian roles; 10 Conception of life; PCA is measure of couples agreement on ENRICH Obstetrical data:; - Complicated pregnancy; - Twin pregnancy; - GA; - C-section (overall); - Normal delivery; - Instrumental delivery; - Ectopic; Interview 12 mo PP Toddler behavior questionnaire | Neither OR nor RR appropriate. ENRICH marital inventory: Both grps scored high but IVF grp scored significantly higher on six of 10 scales. At f/u there was a decline in control grp, with IVF grp scores remaining stable. PCA scores: IVF grp scored higher than control on five of 10 scales during pregnancy, and control grp scored higher on one of ten. No significant differences were detected regarding obstetrical outcomes (except higher incidence of twin gestation in IVF grp), neonatal data, or in outcome interviews between grps. | | | | Comments: No power calculations Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: Adequate description of the cohort: - (no race, ethnicity, diagnosis; no psych issues identified in entire cohort) Use of validated method for genomic test: NA Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: - (but authors plan 4 yr f/u) Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results:
Tabs, Vejnovic, Radunovic, et al., 2004 #42230 | Geographical location: Novi Sad, Serbia Study dates: Jan 1996–Dec 2002 Size of population: IVF 144 Control group 39112 All singletons Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singletons only Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia Eclampsia No definitions of outcomes given | 1) Preeclampsia for IVF vs. spontaneous: | | | | Comments: Unadjusted for maternal age or parity Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Tabs, Vejnovic, Radunovic, et al., 2004 #42230 | Geographical location: Novi Sad, Serbia Study dates: Jan 1996–Dec 2002 Size of population: IVF 144 Control group 39112 All singletons Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singletons only Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia Eclampsia No definitions of outcomes given | | Preecl + | Preecl - | Total
Tabs, Vejnovic, Radunovic, et al., 2004 #42230 | Geographical location: Novi Sad, Serbia Study dates: Jan 1996–Dec 2002 Size of population: IVF 144 Control group 39112 All singletons Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singletons only Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia Eclampsia No definitions of outcomes given | IVF | 3 | 141 | 144
Tabs, Vejnovic, Radunovic, et al., 2004 #42230 | Geographical location: Novi Sad, Serbia Study dates: Jan 1996–Dec 2002 Size of population: IVF 144 Control group 39112 All singletons Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singletons only Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia Eclampsia No definitions of outcomes given | Spont | 158 | 38954 | 39112
Tabs, Vejnovic, Radunovic, et al., 2004 #42230 | Geographical location: Novi Sad, Serbia Study dates: Jan 1996–Dec 2002 Size of population: IVF 144 Control group 39112 All singletons Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singletons only Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia Eclampsia No definitions of outcomes given | Total | 161 | 39095 | 39256
Tabs, Vejnovic, Radunovic, et al., 2004 #42230 | Geographical location: Novi Sad, Serbia Study dates: Jan 1996–Dec 2002 Size of population: IVF 144 Control group 39112 All singletons Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singletons only Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia Eclampsia No definitions of outcomes given | | Value | Lower 95% CI | Upper 95% CI
Tabs, Vejnovic, Radunovic, et al., 2004 #42230 | Geographical location: Novi Sad, Serbia Study dates: Jan 1996–Dec 2002 Size of population: IVF 144 Control group 39112 All singletons Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singletons only Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia Eclampsia No definitions of outcomes given | Rel risk | 5.16 | 1.67 | 15.97
Tabs, Vejnovic, Radunovic, et al., 2004 #42230 | Geographical location: Novi Sad, Serbia Study dates: Jan 1996–Dec 2002 Size of population: IVF 144 Control group 39112 All singletons Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singletons only Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia Eclampsia No definitions of outcomes given | 2) Eclampsia for IVF v. spontaneous:
Tabs, Vejnovic, Radunovic, et al., 2004 #42230 | Geographical location: Novi Sad, Serbia Study dates: Jan 1996–Dec 2002 Size of population: IVF 144 Control group 39112 All singletons Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singletons only Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia Eclampsia No definitions of outcomes given | | Eclamp + | Eclamp - | Total
Tabs, Vejnovic, Radunovic, et al., 2004 #42230 | Geographical location: Novi Sad, Serbia Study dates: Jan 1996–Dec 2002 Size of population: IVF 144 Control group 39112 All singletons Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singletons only Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia Eclampsia No definitions of outcomes given | IVF | 1 | 143 | 144
Tabs, Vejnovic, Radunovic, et al., 2004 #42230 | Geographical location: Novi Sad, Serbia Study dates: Jan 1996–Dec 2002 Size of population: IVF 144 Control group 39112 All singletons Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singletons only Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia Eclampsia No definitions of outcomes given | Spont | 22 | 39090 | 39112
Tabs, Vejnovic, Radunovic, et al., 2004 #42230 | Geographical location: Novi Sad, Serbia Study dates: Jan 1996–Dec 2002 Size of population: IVF 144 Control group 39112 All singletons Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singletons only Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia Eclampsia No definitions of outcomes given | Total | 23 | 39233 | 39256
Tabs, Vejnovic, Radunovic, et al., 2004 #42230 | Geographical location: Novi Sad, Serbia Study dates: Jan 1996–Dec 2002 Size of population: IVF 144 Control group 39112 All singletons Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singletons only Exclusion criteria: NR | Definition(s) of outcome(s): Preeclampsia Eclampsia No definitions of outcomes given | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 12.35 | 1.68 | 90.98
Terry, Willett, Rich-Edwards, et al., 2006 #56150 | Geographical location: US (Nurses Health Study II) Study dates: Enrolled 1989, followup 1993-2001 Size of population (no. of patients): 116,741 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Registered nurses; - Age 25–42 at; Exclusion criteria:; - History of breast or other cancer; - No height/weight recorded; - Fertility-status unclear | Definition(s) of outcome(s): Breast cancer cases, confirmed by pathology report in 99% of cases | 1) Adjusted* hazard ratios, by diagnosis: | | | | Comments:; - Exposure by self-reported (confirmed in 95% of sample of 40 records); - Use of ovulatory drugs by non-ovulatory disorder subjects not assessed; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: - Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Terry, Willett, Rich-Edwards, et al., 2006 #56150 | Geographical location: US (Nurses Health Study II) Study dates: Enrolled 1989, followup 1993-2001 Size of population (no. of patients): 116,741 Study type: Cohort | | Definition(s) of outcome(s): Breast cancer cases, confirmed by pathology report in 99% of cases | | HR | 95% CI
Terry, Willett, Rich-Edwards, et al., 2006 #56150 | Geographical location: US (Nurses Health Study II) Study dates: Enrolled 1989, followup 1993-2001 Size of population (no. of patients): 116,741 Study type: Cohort | | Definition(s) of outcome(s): Breast cancer cases, confirmed by pathology report in 99% of cases | No infertilty | 1.00 (ref)
Terry, Willett, Rich-Edwards, et al., 2006 #56150 | Geographical location: US (Nurses Health Study II) Study dates: Enrolled 1989, followup 1993-2001 Size of population (no. of patients): 116,741 Study type: Cohort | | Definition(s) of outcome(s): Breast cancer cases, confirmed by pathology report in 99% of cases | Infertility due to ovulatory disorder: | 0.75 | 0.59,0.96
Terry, Willett, Rich-Edwards, et al., 2006 #56150 | Geographical location: US (Nurses Health Study II) Study dates: Enrolled 1989, followup 1993-2001 Size of population (no. of patients): 116,741 Study type: Cohort | | Definition(s) of outcome(s): Breast cancer cases, confirmed by pathology report in 99% of cases | Other cause infertility | 1.05 | 0.76,1.45
Terry, Willett, Rich-Edwards, et al., 2006 #56150 | Geographical location: US (Nurses Health Study II) Study dates: Enrolled 1989, followup 1993-2001 Size of population (no. of patients): 116,741 Study type: Cohort | | Definition(s) of outcome(s): Breast cancer cases, confirmed by pathology report in 99% of cases | *Adjusted for age, height, current body mass index, body mass index at age 18 years, family history of breast cancer, history of benign breast disease, age at menarche, parity, age at first birth, oral contraceptive use, alcohol use, and physical activity.
Terry, Willett, Rich-Edwards, et al., 2006 #56150 | Geographical location: US (Nurses Health Study II) Study dates: Enrolled 1989, followup 1993-2001 Size of population (no. of patients): 116,741 Study type: Cohort | | Definition(s) of outcome(s): Breast cancer cases, confirmed by pathology report in 99% of cases | 2) Adjusted* hazard ratios, by ovulation induction:
Terry, Willett, Rich-Edwards, et al., 2006 #56150 | Geographical location: US (Nurses Health Study II) Study dates: Enrolled 1989, followup 1993-2001 Size of population (no. of patients): 116,741 Study type: Cohort | | Definition(s) of outcome(s): Breast cancer cases, confirmed by pathology report in 99% of cases | | HR | 95% CI
Terry, Willett, Rich-Edwards, et al., 2006 #56150 | Geographical location: US (Nurses Health Study II) Study dates: Enrolled 1989, followup 1993-2001 Size of population (no. of patients): 116,741 Study type: Cohort | | Definition(s) of outcome(s): Breast cancer cases, confirmed by pathology report in 99% of cases | No infertilty | 1.00 (ref)
Terry, Willett, Rich-Edwards, et al., 2006 #56150 | Geographical location: US (Nurses Health Study II) Study dates: Enrolled 1989, followup 1993-2001 Size of population (no. of patients): 116,741 Study type: Cohort | | Definition(s) of outcome(s): Breast cancer cases, confirmed by pathology report in 99% of cases | Ovulatory infertility no induction | 1.37 | 0.94,1.99
Terry, Willett, Rich-Edwards, et al., 2006 #56150 | Geographical location: US (Nurses Health Study II) Study dates: Enrolled 1989, followup 1993-2001 Size of population (no. of patients): 116,741 Study type: Cohort | | Definition(s) of outcome(s): Breast cancer cases, confirmed by pathology report in 99% of cases | Ovulatory infertility, ovulation induction | 0.60 | 0.42,0.85
Terry, Willett, Rich-Edwards, et al., 2006 #56150 | Geographical location: US (Nurses Health Study II) Study dates: Enrolled 1989, followup 1993-2001 Size of population (no. of patients): 116,741 Study type: Cohort | | Definition(s) of outcome(s): Breast cancer cases, confirmed by pathology report in 99% of cases | Other infertilty | 0.67 | 0.35,1.25
*Adjusted for age, height, current body mass index, body mass index at age 18 years, family history of breast cancer, history of benign breast disease, age at menarche, parity, age at first birth, oral contraceptive use, alcohol use, and physical activity.
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | 1) Relative risk for positive results (risk > 1/300), based on nuchal translucency + free β-hCG + PAPP-A + maternal age, IVF: | | | | Comments: No adjustment for multiple comparisons Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | | Out + | Out - | Total
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | IVF + | 12 | 118 | 130
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | Control | 28 | 886 | 914
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | Total | 40 | 1004 | 1044
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | | Value | Lower 95% CI | Upper 95% CI
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | Rel risk | 3.01 | 1.57 | 5.78
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | After adjustment for maternal age, relative risk = 1.67 (0.79, 3.54)
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | 2) Relative risk for positive results (risk > 1/300), based on nuchal translucency + free β-hCG + PAPP-A + maternal age, ICSI:
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | | Out + | Out - | Total
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | Exp + | 7 | 47 | 54
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | Exp - | 28 | 886 | 914
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | Total | 35 | 933 | 968
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | | Value | Lower 95% CI | Upper 95% CI
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | Rel risk | 4.23 | 1.94 | 9.24
Tul and Novak-Antolic, 2006 #56290 | Geographical location: Ljubljana, Slovenia Study dates: Feb 1999–Aug 2001 Size of population (no. of patients): 914 spontaneous 130 IVF 54 ICSI Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Known mode of conception; - Undergoing screening; Exclusion criteria: NR | Definition(s) of outcome(s): 1^st^ and 2^nd^ trimester test results (nuchal translucency, PAPP-A, inhibin A, free β-hCG) | After adjustment for maternal age, relative risk = 2.78 (1.1, 7.0)
3) PAPP-A lower, inhibin significantly higher in ART groups compared to spontaneous.
Tulandi, Martin, Al-Fadhli, et al., 2006 #56300 | Geographical location: Montreal, London, and Toronto, Canada Study dates: Jan 2001–Dec 2005 Size of population (no. of patients): 931 Study type: Cohort | Age: Mean (SD): Letrozole: 33.1 (5.3); Letrozole + FSH 32.4 (5.4); Clomiphene 32.9 (4.5); Clompihene +FSH 33.9 (4.9) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Ovulation induction or augmentation for timed intercourse or intrauterine insemination with either letrozole or CC administered orally for 5 days from day 3 to 7 of the cycle. Exclusion criteria: IVF | Definition(s) of outcome(s): Major and minor malformations based on WHO criteria | 1) Major malformations, letrozole vs clomiphene: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Tulandi, Martin, Al-Fadhli, et al., 2006 #56300 | Geographical location: Montreal, London, and Toronto, Canada Study dates: Jan 2001–Dec 2005 Size of population (no. of patients): 931 Study type: Cohort | | Definition(s) of outcome(s): Major and minor malformations based on WHO criteria | | Out + | Out - | Total
Tulandi, Martin, Al-Fadhli, et al., 2006 #56300 | Geographical location: Montreal, London, and Toronto, Canada Study dates: Jan 2001–Dec 2005 Size of population (no. of patients): 931 Study type: Cohort | | Definition(s) of outcome(s): Major and minor malformations based on WHO criteria | Letrozole | 6 | 508 | 514
Tulandi, Martin, Al-Fadhli, et al., 2006 #56300 | Geographical location: Montreal, London, and Toronto, Canada Study dates: Jan 2001–Dec 2005 Size of population (no. of patients): 931 Study type: Cohort | | Definition(s) of outcome(s): Major and minor malformations based on WHO criteria | Clomiphene | 12 | 385 | 397
Tulandi, Martin, Al-Fadhli, et al., 2006 #56300 | Geographical location: Montreal, London, and Toronto, Canada Study dates: Jan 2001–Dec 2005 Size of population (no. of patients): 931 Study type: Cohort | | Definition(s) of outcome(s): Major and minor malformations based on WHO criteria | Total | 18 | 893 | 911
Tulandi, Martin, Al-Fadhli, et al., 2006 #56300 | Geographical location: Montreal, London, and Toronto, Canada Study dates: Jan 2001–Dec 2005 Size of population (no. of patients): 931 Study type: Cohort | | Definition(s) of outcome(s): Major and minor malformations based on WHO criteria | | Value | Lower 95% CI | Upper 95% CI
Tulandi, Martin, Al-Fadhli, et al., 2006 #56300 | Geographical location: Montreal, London, and Toronto, Canada Study dates: Jan 2001–Dec 2005 Size of population (no. of patients): 931 Study type: Cohort | | Definition(s) of outcome(s): Major and minor malformations based on WHO criteria | Rel risk | 0.39 | 0.15 | 1.02
Tulandi, Martin, Al-Fadhli, et al., 2006 #56300 | Geographical location: Montreal, London, and Toronto, Canada Study dates: Jan 2001–Dec 2005 Size of population (no. of patients): 931 Study type: Cohort | | Definition(s) of outcome(s): Major and minor malformations based on WHO criteria | 2) Minor malformations, letrozole vs clomiphene:
Tulandi, Martin, Al-Fadhli, et al., 2006 #56300 | Geographical location: Montreal, London, and Toronto, Canada Study dates: Jan 2001–Dec 2005 Size of population (no. of patients): 931 Study type: Cohort | | Definition(s) of outcome(s): Major and minor malformations based on WHO criteria | | Out + | Out - | Total
Tulandi, Martin, Al-Fadhli, et al., 2006 #56300 | Geographical location: Montreal, London, and Toronto, Canada Study dates: Jan 2001–Dec 2005 Size of population (no. of patients): 931 Study type: Cohort | | Definition(s) of outcome(s): Major and minor malformations based on WHO criteria | Letrozole | 8 | 506 | 514
Tulandi, Martin, Al-Fadhli, et al., 2006 #56300 | Geographical location: Montreal, London, and Toronto, Canada Study dates: Jan 2001–Dec 2005 Size of population (no. of patients): 931 Study type: Cohort | | Definition(s) of outcome(s): Major and minor malformations based on WHO criteria | Clomiphene | 7 | 390 | 397
Tulandi, Martin, Al-Fadhli, et al., 2006 #56300 | Geographical location: Montreal, London, and Toronto, Canada Study dates: Jan 2001–Dec 2005 Size of population (no. of patients): 931 Study type: Cohort | | Definition(s) of outcome(s): Major and minor malformations based on WHO criteria | Total | 15 | 896 | 911
Tulandi, Martin, Al-Fadhli, et al., 2006 #56300 | Geographical location: Montreal, London, and Toronto, Canada Study dates: Jan 2001–Dec 2005 Size of population (no. of patients): 931 Study type: Cohort | | Definition(s) of outcome(s): Major and minor malformations based on WHO criteria | | Value | Lower 95% CI | Upper 95% CI
Tulandi, Martin, Al-Fadhli, et al., 2006 #56300 | Geographical location: Montreal, London, and Toronto, Canada Study dates: Jan 2001–Dec 2005 Size of population (no. of patients): 931 Study type: Cohort | | Definition(s) of outcome(s): Major and minor malformations based on WHO criteria | Rel risk | 0.88 | 0.32 | 2.41
3) Similar to population risk (2–3%)
Tully, Moffitt, and Caspi, 2003 #17200 | Geographical location: England, Wales Study dates: Jan 1994–Dec 1995 Size of population: 121 families of 5 yo IVF or ovulation induction (OI) twins 121 naturally conceived (NC) 5 yo same-sex twins Study type: Case-control Birth register of twins used to identify cases (twins conceived by IVF/OI), controls (NC). Matched for gender, zygosity, ethnicity, family income & occupation, parental relationship, birth order, birthwt, mat age, # children in family | Age: (maternal) Mean (SD): Cases: 36.0 (4.95) Controls: 35.6 (4.65) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Subset of participants in Environmental Risk Longitudinal Twin Study, drawn from births 1994 & 1995 in England & Wales; - “IVF” included IVF, IUI, and GIFT; Exclusion criteria:; - Not Living in England or Wales; - Not English-speaking; - Not being reared by at least 1 biological parent; - Opposite sex twins | Definition(s) of outcome(s): Researchers visited homes in teams of 2 for total of 2–3 hrs. Had degrees in behavioral science and experience in psychology, anthropology, or nursing. Blinded to method of conception. Also gave questionnaire to teachers (93% response rate) Assessed:; - Parental adjustment (quality of parental relationship, quarrelling, abuse, support, social support, depression);; - Parenting (consistency, physical discipline, warmth, negativity);; - Children's behavior (Achenbach Child Behavior Checklist, Rutter Child Scales, DSM-IV) | No significant difference in any variable by method of conception, except inconsistency in discipline: NC group mean 2.11 (SD 1.57), IVF/OI group mean 1.58 (1.26). No categorical variables to analyze with 2×2 tables | | | | Comments:; - 71% of twins born in 1994-5 joined register; - Well-matched with respect to potential confounders; - Trained researchers, blinded to method of conception; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: + Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Tummers, De Sutter, and Dhont, 2003 #16040 | Geographical location: Ghent, Belgium Study dates: 1993-2000 Size of population: 1200 singletons, 397 twins Study type: Cohort Records of all IVF/ICSI pts treated in 1 center reviewed, SAb rates in singletons compared to twins | Age: Mean (SD): singletons 31.3 (0.7), twins 30.7 (0.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR, but “not signif diff between grps” Inclusion criteria: Pts followed until ≥ 12 wk with reliable outcome info Exclusion criteria: Followed until < 12 wk gestation, no outcome information available, biochemical & ectopic pregnancies, triplets | Definition(s) of outcome(s): SAb = blighted ovum or fetal demise Ongoing preg = delivery > 25 wk For twins, separate data given for partial SAb (vanishing twin) or complete; overall considered incidence of SAb for each sac separately | 1) Overall risk for SAb: | | | | Comments: Only 64% had f/u & reliable outcome info; data on dropout pt's characteristics not shown. Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | | SAb + | SAb - | Total
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | Twins | 88 | 706 | 794
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | Single | 262 | 938 | 1200
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | Total | 350 | 1644 | 1994
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | | Value | Lower 95% CI | Upper 95% CI
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | Rel risk | 0.51 | 0.41 | 0.64
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | Data given for risk of SAb by gestational age in %, but not sure whether the denominator is total number or number remaining pregnancies at that gest age. Difference persisted until 13 wks, when singleton rate = twin rate.
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | 2) Risk for SAb stratified by maternal age:
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | | SAb + | SAb - | Total
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | Twins > 35 | 17 | 73 | 90
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | Single > 35 | 59 | 126 | 185
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | Total | 76 | 199 | 275
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | | Value | Lower 95% CI | Upper 95% CI
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | Rel risk | 0.59 | 0.37 | 0.95
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | | SAb + | SAb - | Total
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | Twins ≤ 35 | 67 | 637 | 704
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | Single ≤ 35 | 201 | 814 | 1015
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | Total | 268 | 1451 | 1719
Tummers, De Sutter, and Dhont, 2003 #16040 | | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.48 | 0.37 | 0.62
Tworoger, Fairfield, Colditz, et al., 2007 #72700 | Geographical location: US (multiple sites) Study dates: 1980–May 2004 Size of population (no. of patients): 121,700 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Ovarian cancer (validated through medical records, death certificates) | 1) Adjusted odds ratio (adjusted for Adjusted for age (continuous), body mass index (< 21, 21 to < 23, 23 to < 25, 25 to < 30, ≥ 30 kg/m2), parity (continuous), history of tubal ligation (ever/never), smoking history (never, current, past), age at menarche (< 11, 11, 12, ≥ 13 years), age at menopause (premenopausal, < 45, 45–49, 50–52, 53–54, ≥ 55 years), duration of postmenopausal hormone use (continuous), and duration of oral contraceptive use (continuous) Female infertility: 1.36 (1.07, 1.75) Male infertility: 1.23 (0.68, 2.25) | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size:+ Adequate description of the cohort: + Use of validated method for ascertaining exposure: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) +and reporting of results:
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | Age: Mean (SD): 30.09 (4.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Pregnancy by u/s with ≥ 8 mm sac with yolk sac ≥ 2 mm Exclusion criteria: Outside f/u, monochorionic, frozen embryo transfer, quintuplets | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | Results stratified by age and described as % of multiples that had any loss in number of gestational sacs | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | 1) Twins (2 gestational sacs):
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | | Loss of any gsacs + | Loss of any gsacs - | Total
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | Age ≥ 35 | 52 | 173 | 225
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | Age < 35 | 106 | 533 | 639
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | Total | 158 | 706 | 864
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | | Value | Lower 95% CI | Upper 95% CI
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | Rel risk | 1.39 | 1.04 | 1.87
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | 2) Triplets (3 gestational sacs):
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | | Loss of any gsacs + | Loss of any gsacs - | Total
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | Age ≥ 35 | 16 | 76 | 92
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | Age < 35 | 53 | 293 | 346
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | Total | 69 | 369 | 438
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | | Value | Lower 95% CI | Upper 95% CI
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | Rel risk | 1.14 | 0.68 | 1.89
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | 3) Quadruplets (4 gestational sacs):
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | | Loss of any gsacs + | Loss of any gsacs - | Total
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | Age ≥ 35 | 4 | 22 | 26
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | Age < 35 | 17 | 103 | 120
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | Total | 21 | 125 | 146
Ulug, Jozwiak, Mesut, et al., 2004 #14040 | Geographical location: Istanbul, Turkey Study dates: 1997-2002 Size of population: 1448 pregnancies from ICSI with multiple gestation by early u/s Study type: Retrospective cohort | | Definition(s) of outcome(s): Gestational sac loss = resorption of a gestational sac and cessation or lack of detection of cardiac activity | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.09 | 0.40 | 2.96
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | 1) All-cause deaths for IVF vs. spontaneous: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: +/- Analysis (multivariate adjustments) and reporting of results: -
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | | Death + | Death - | Total
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | IVF | 72 | 17040 | 17112
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | Spont | 51 | 7782 | 7833
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | Total | 123 | 24822 | 24945
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | | Value | Lower 95% CI | Upper 95% CI
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | Rel risk | 0.65 | 0.45 | 0.92
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | 2) Cancer deaths for IVF vs. spontaneous:
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | | Death + | Death - | Total
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | IVF | 51 | 21035 | 21086
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | Spont | 29 | 8585 | 8614
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | Total | 80 | 29620 | 29700
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | | Value | Lower 95% CI | Upper 95% CI
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | Rel risk | 0.72 | 0.46 | 1.13
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | 3) Breast cancer deaths for IVF vs. spontaneous:
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | | Death + | Death - | Total
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | IVF | 26 | 21060 | 21086
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | Spont | 9 | 8605 | 8614
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | Total | 35 | 29665 | 29700
Venn, Hemminki, Watson, et al., 2001 #3380 | Geographical location: Australia Study dates: Women from IVF clinics before January 1, 1994 Size of population: 29,700 women No IVF: 21,086 IVF: 8614 Study type: Cohort | Age: Median (range) at entry: IVF: 32 (18–54) No IVF: 30 (18–51) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Female death Exclusion criteria: NR | Definition(s) of outcome(s): Death, by cause | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.18 | 0.55 | 2.52
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | Geographical location: Brussels, Belgium Study dates: Jan 1994–Dec 2000 Size of population: 274 pregnancies (70 NOA, 204 OA) Study type: Cohort 2 cohorts defined histologically as non-obstructive azoospermia (NOA) = complete or incomplete maturation arrest, complete or incomplete germ cell aplasia, and tubular sclerosis and atrophy; or obstructive azoospermia (OA) | Age: Mean (range): NOA 31.4 (29.7–33.0) OA 32.7 (31.8–33.6) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Pregnant pts whose male partner had testicular sperm recovery for ICSI Exclusion criteria: Klinefelter's syndrome males | Definition(s) of outcome(s): Abortion = loss < 20wk PTD = del < 37wk LBW < 2500 g IUFD ≥ 20 wk Neonatal death ≤ 1 wk Major malformation = causing death or functional impairment, or requiring surgical correction | No difference between groups in any outcome studied. | | | | Comments: 8% lost to followup Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for genomic test: NR Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | 1) LBW:
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | | LBW + | LBW - | Total
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | NOA | 20 | 39 | 59
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | OA | 59 | 133 | 192
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | Total | 79 | 172 | 251
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | | Value | Lower 95% CI | Upper 95% CI
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | Rel risk | 1.10 | 0.73 | 1.67
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | 2) Selective reduction:
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | | Sel red + | Sel red - | Total
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | NOA | 0.5 | 70 | 70.5
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | OA | 1 | 203 | 204
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | Total | 1.5 | 273 | 274.5
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | | Value | Lower 95% CI | Upper 95% CI
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | Rel risk | 1.45 | 0.05 | 42.66
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | 3) IUFD:
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | | IUFD + | IUFD - | Total
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | NOA | 3 | 58 | 61
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | OA | 3 | 193 | 196
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | Total | 6 | 251 | 257
Vernaeve, Bonduelle, Tournaye, et al., 2003 #15420 | | | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 3.21 | 0.67 | 15.51
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | 1) Preterm birth ovarian stimulation: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | | ptb+ | ptb- | Total
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | ov stim | 385 | 325 | 710
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | spontaneous | 1314 | 1601 | 2915
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | Total | 1699 | 1926 | 3625
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | | Value | Lower 95% CI | Upper 95% CI
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | Rel risk | 1.20 | 1.11 | 1.30
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | 2) Low birthweight ovarian stimulation:
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | | lbwt+ | lbwt- | Total
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | ov stim | 476 | 234 | 710
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | spontaneous | 1803 | 1112 | 2915
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | Total | 2279 | 1346 | 3625
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | | Value | Lower 95% CI | Upper 95% CI
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | Rel risk | 1.08 | 1.02 | 1.15
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | 3) Low birthweight IVF/ICSI:
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | | lbwt+ | lbwt- | Total
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | IVF/ICSI | 515 | 228 | 743
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | spontaneous | 1803 | 1112 | 2915
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | Total | 2318 | 1340 | 3658
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | | Value | Lower 95% CI | Upper 95% CI
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | Rel risk | 1.12 | 1.06 | 1.18
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | 4) Preterm birth IVF/ICSI:
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | | ptb+ | ptb- | Total
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | IVF/ICSI | 441 | 302 | 743
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | spontaneous | 1803 | 1112 | 2915
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | Total | 2244 | 1414 | 3658
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | | Value | Lower 95% CI | Upper 95% CI
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | Rel risk | 0.96 | 0.90 | 1.03
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | 5) Preterm birth 2 ART methods compared:
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | | ptb+ | ptb- | Total
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | IVF/ICSI | 441 | 302 | 743
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | ov stim | 385 | 325 | 710
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | Total | 826 | 627 | 1453
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | | Value | Lower 95% CI | Upper 95% CI
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | Rel risk | 1.09 | 1.00 | 1.20
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | 6) Low birthweight 2 ART methods compared:
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | | lbwt+ | lbwt- | Total
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | IVF/ICSI | 515 | 228 | 743
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | ov stim | 476 | 234 | 710
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | Total | 991 | 462 | 1453
Verstraelen, Goetgeluk, Derom, et al., 2005 #40620 | Geographical location: Belgium Study dates: 1976-2002 Size of population (no. of patients): 2915 spontaneous twins 1453 ART twins (710 ovarian stimulation, 743 IVF/ICSI) Study type: Cohort | Age: Natural conception 28.6 (4.5) Ovarian stim 28.7 (3.7) IVF/ICSI 31.5 (3.4) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twins Exclusion criteria: Missing data | Definition(s) of outcome(s): Preterm birth < 37 wks Low birthweight < 2500gm | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.03 | 0.96 | 1.11
Vollenhoven, Clark, Kovacs, et al., 2000 #7640 | Geographical location: Australia Study dates: 1990-97 Size of population: 60 PCOS patients 60 spontaneous Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 14% PCOS: 67% Other: Hypogonadotrophic hypogonadism: 12% Eugonadotrophic hypogonadism: 7% Inclusion criteria: Controls matched for age, BMI, ethnicity; induction after gonadotropins for PCOS patients Exclusion criteria: NR | Definition(s) of outcome(s): Gestational diabetes based on 75 g glucose challenge, confirmed by 75 g fasting & 2 hr glucose tolerance test | 1) Gestational diabetes in PCOS vs. spontaneous conception: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Vollenhoven, Clark, Kovacs, et al., 2000 #7640 | Geographical location: Australia Study dates: 1990-97 Size of population: 60 PCOS patients 60 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Gestational diabetes based on 75 g glucose challenge, confirmed by 75 g fasting & 2 hr glucose tolerance test | | GDM + | GDM - | Total
Vollenhoven, Clark, Kovacs, et al., 2000 #7640 | Geographical location: Australia Study dates: 1990-97 Size of population: 60 PCOS patients 60 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Gestational diabetes based on 75 g glucose challenge, confirmed by 75 g fasting & 2 hr glucose tolerance test | PCOS | 13.2 | 46.8 | 60
Vollenhoven, Clark, Kovacs, et al., 2000 #7640 | Geographical location: Australia Study dates: 1990-97 Size of population: 60 PCOS patients 60 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Gestational diabetes based on 75 g glucose challenge, confirmed by 75 g fasting & 2 hr glucose tolerance test | Spont | 10.2 | 49.8 | 60
Vollenhoven, Clark, Kovacs, et al., 2000 #7640 | Geographical location: Australia Study dates: 1990-97 Size of population: 60 PCOS patients 60 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Gestational diabetes based on 75 g glucose challenge, confirmed by 75 g fasting & 2 hr glucose tolerance test | Total | 23.4 | 96.6 | 120
Vollenhoven, Clark, Kovacs, et al., 2000 #7640 | Geographical location: Australia Study dates: 1990-97 Size of population: 60 PCOS patients 60 spontaneous Study type: Cohort | | Definition(s) of outcome(s): Gestational diabetes based on 75 g glucose challenge, confirmed by 75 g fasting & 2 hr glucose tolerance test | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.29 | 0.62 | 2.70
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 16% Endometriosis: 9% Male factor: 35% Tubal factor: 34% PCOS: 37% Other: 6% Inclusion criteria: Treated in Repro Med Unit (with IVF, GIFT, or ICSI) Exclusion criteria: PCOS status or BMI not assessed | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | 1) SAb by mode of conception - conventional IVF versus ICSI for male factor only: | | | | Comments: Confounders explored only by PCOS vs non-PCOS (which was objective of study), not by mode of conception Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for genomic test: n/a Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | | SAb + | SAb -
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | ICSI | 43 | 289 | 332
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | IVF | 117 | 335 | 452
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | | 160 | 624 | 784
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | | | Lower 95% CI | Upper 95 % CI
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | Rel risk | 0.50 | 0.36 | 0.69
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | 2) SAb by mode of conception - conventional IVF versus ICSI for other etiology:
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | | SAb + | SAb -
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | Study drug | 9 | 47 | 56
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | Control | 117 | 335 | 452
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | | 126 | 382 | 508
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | | | Lower 95% CI | Upper 95 % CI
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | Rel risk | 0.62 | 0.33 | 1.15
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | 3) SAb by mode of conception - ICSI for male factor only versus for other etiology:
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | | SAb + | SAb - | Total
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | ICSI-male | 43 | 289 | 332
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | ICSI-other | 9 | 47 | 56
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | Total | 52 | 336 | 388
Wang, Davies, and Norman, 2001 #3420 | Geographical location: Woodville, Australia Study dates: 1987-99 Size of population: 1018 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Pregnancy = embryonic sac by US at 4–6 wk after transfer SAb = pregnancy failing to reach 20 wk, excluding ectopics or induced Ab | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 0.81 | 0.42 | 1.56
Wang, Norman, and Kristiansson, 2002 #2420 | Geographical location: Uppsala, Sweden Study dates: 1986 - 1998 Size of population: 1,015 births by “low technology treatment”; - IUI; - donor insemination; - 1,019 by “high technology treatment”; - IVF; - ICSI; - GIFT; - 1,019 births by natural conception; Study type: Cohort (retrospective) | Age: Mean (SD): Ctrls 31.9 4.1) Low tech 30.9 (4.1) High tech 32.5 (4.1) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Infertile pts treated in this Unit; births defined as delivery >20wks or fetus >=400g Exclusion criteria: Multiple births | Definition(s) of outcome(s): “Definitions of threatened miscarriage, antepartum hemorrhage and congenital malformations based on recommendations of the WHO” Very preterm birth < 32wks Preterm < 37wks Elective / emergent C/S not defined | 1) Threatened AB by mode of conception: low technology versus naturally-conceived: | | | | Comments:; - Data on some confounders (previous preterm birth, previous SAB, race, socio-economic factors, smoking status) not available for control grp.; - “High tech” women older, longer infertile period; Did not differentiate ICSI from IVF Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for genomic test: n/a Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: - (no mention of when/how congenital malformations dx';d) Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | ThrAB+ | ThrAB- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Low | 56 | 959 | 1015
Wang, Norman, and Kristiansson, 2002 #2420 | | | | NC | 34 | 985 | 1019
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 90 | 1944 | 2034
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Odds rat | 1.69 | 1.09 | 2.61
Wang, Norman, and Kristiansson, 2002 #2420 | | | | 2) Threatened AB by mode of conception: high technology versus naturally-conceived:
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | ThrAB+ | ThrAB- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | High | 90 | 929 | 1019
Wang, Norman, and Kristiansson, 2002 #2420 | | | | NC | 34 | 985 | 1019
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 124 | 1914 | 2038
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Odds rat | 2.81 | 1.87 | 4.21
Wang, Norman, and Kristiansson, 2002 #2420 | | | | 3) Threatened AB by mode of conception: high technology versus low:
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | ThrAB+ | ThrAB- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | High | 90 | 929 | 1019
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Low | 56 | 959 | 1015
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 146 | 1888 | 2034
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Odds rat | 1.66 | 1.17 | 2.34
Wang, Norman, and Kristiansson, 2002 #2420 | | | | 4) Congenital malformation by mode of conception: low technology versus naturally-conceived:
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Malf+ | Malf- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Low | 49 | 966 | 1015
Wang, Norman, and Kristiansson, 2002 #2420 | | | | NC | 46 | 973 | 1019
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 95 | 1939 | 2034
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Odds rat | 1.07 | 0.71 | 1.62
Wang, Norman, and Kristiansson, 2002 #2420 | | | | 5) Congenital malformation by mode of conception: high technology versus naturally-conceived:
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Malf+ | Malf- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | High | 44 | 975 | 1019
Wang, Norman, and Kristiansson, 2002 #2420 | | | | NC | 46 | 973 | 1019
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 90 | 1948 | 2038
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Odds rat | 0.95 | 0.63 | 1.46
Wang, Norman, and Kristiansson, 2002 #2420 | | | | 6) Congenital malformation by mode of conception: high technology versus low:
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Malf+ | Malf- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | High | 44 | 975 | 1019
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Low | 49 | 966 | 1015
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 93 | 1941 | 2034
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Odds rat | 0.89 | 0.59 | 1.35
Wang, Norman, and Kristiansson, 2002 #2420 | | | | 7) Preterm birth via elective C/S by mode of conception: low technology versus naturally-conceived:
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | CS+ | CS- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Low | 3 | 109 | 112
Wang, Norman, and Kristiansson, 2002 #2420 | | | | NC | 2 | 93 | 95
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 5 | 202 | 207
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Odds rat | 1.28 | 0.21 | 7.82
Wang, Norman, and Kristiansson, 2002 #2420 | | | | 8) Preterm birth via elective C/S by mode of conception: high technology versus naturally-conceived:
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | CS+ | CS- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | High | 6 | 148 | 154
Wang, Norman, and Kristiansson, 2002 #2420 | | | | NC | 2 | 93 | 95
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 8 | 241 | 249
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Odds rat | 1.89 | 0.37 | 9.54
Wang, Norman, and Kristiansson, 2002 #2420 | | | | 9) Preterm birth via elective C/S by mode of conception: high technology versus low:
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | CS+ | CS- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | High | 6 | 148 | 154
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Low | 3 | 109 | 112
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 9 | 257 | 266
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Odds rat | 1.47 | 0.36 | 6.02
Wang, Norman, and Kristiansson, 2002 #2420 | | | | 10) Preterm birth via emergent C/S by mode of conception: low technology versus naturally-conceived:
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | CS+ | CS- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Low | 26 | 13 | 39
Wang, Norman, and Kristiansson, 2002 #2420 | | | | NC | 6 | 15 | 21
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 32 | 28 | 60
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Odds rat | 5.00 | 1.57 | 15.91
Wang, Norman, and Kristiansson, 2002 #2420 | | | | 11) Preterm birth via emergent C/S by mode of conception: high technology versus naturally-conceived:
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | CS+ | CS- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | High | 32 | 17 | 49
Wang, Norman, and Kristiansson, 2002 #2420 | | | | NC | 6 | 15 | 21
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 38 | 32 | 70
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Odds rat | 4.71 | 1.54 | 14.35
Wang, Norman, and Kristiansson, 2002 #2420 | | | | 12) Preterm birth via emergent C/S by mode of conception: high technology versus low:
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | CS+ | CS- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | High | 32 | 17 | 49
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Low | 26 | 13 | 39
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 58 | 30 | 88
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Odds rat | 0.94 | 0.39 | 2.29
Wang, Norman, and Kristiansson, 2002 #2420 | | | | 13) Spontaneous preterm birth by mode of conception: low technology versus naturally-conceived:
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | PTB+ | PTB- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Low | 40 | 527 | 567
Wang, Norman, and Kristiansson, 2002 #2420 | | | | NC | 38 | 622 | 660
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 78 | 1149 | 1227
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Odds rat | 1.24 | 0.79 | 1.97
Wang, Norman, and Kristiansson, 2002 #2420 | | | | 14) Spontaneous preterm birth by mode of conception: high technology versus naturally-conceived:
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | PTB+ | PTB- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | High | 71 | 498 | 569
Wang, Norman, and Kristiansson, 2002 #2420 | | | | NC | 38 | 622 | 660
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 109 | 1120 | 1229
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Odds rat | 2.33 | 1.55 | 3.52
Wang, Norman, and Kristiansson, 2002 #2420 | | | | 15) Spontaneous preterm birth by mode of conception: high technology versus low:
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | PTB+ | PTB- | Total
Wang, Norman, and Kristiansson, 2002 #2420 | | | | High | 71 | 498 | 569
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Low | 40 | 527 | 567
Wang, Norman, and Kristiansson, 2002 #2420 | | | | Total | 111 | 1025 | 1136
Wang, Norman, and Kristiansson, 2002 #2420 | | | | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.88 | 1.25 | 2.82
Whiteman, Murphy, Hey, et al. 2000 #6510 | Geographical location: Oxford, UK Study dates: 1970 - 1987 Size of population: 694 index pregnancies 694 ctrls Study type: Case-control NTD cases identified from 3 main sources: Oxford Record Linkage Study, Local AFP screening program, Abortions/congenital malformations data set. Also from pds surgery unit records, perinatal path reports, regional genetics unit, home birth & delivery suite registers. For each case, randomly selected ctrl from Oxford Record Linkage Study database, matched for maternal age and yr of NTD event. In every instance in which case's pregnancy was terminated following NTD dx, ctrl fetus had to be at least of same GA | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Women whose pregnancies affected by NTD alone or in combination with other defects in liveborn or stillborn child, late miscarriage, or terminated pregnancy and were dx'd in Oxfordshire or West Berkshire, England Exclusion criteria: Women whose pregnancies had terminated were excluded from control grp | Definition(s) of outcome(s): NTD = anencephaly, encephalocele, spina bifida aperta, or spina bifida occulta | No signif difference btw cases & ctrls for h/o subfertility, treatment for subfertility, clomid treatment | | | | Comment:; - Estimate >90% completeness; - Data abstracter not blinded; - Terminations excluded from control grp, but if anything this would increase chance of finding a difference between grps; - No mention of DM status; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: - Verification that the control is free of cancer: + Comparability of cases and controls with respect to potential confounders: - Validated dietary assessment method: n/a Appropriateness of statistical analyses: +
Whiteman, Murphy, Hey, et al. 2000 #6510 | | | Definition(s) of outcome(s): NTD = anencephaly, encephalocele, spina bifida aperta, or spina bifida occulta | 1) Treatment for subfertility this preg:
Whiteman, Murphy, Hey, et al. 2000 #6510 | | | Definition(s) of outcome(s): NTD = anencephaly, encephalocele, spina bifida aperta, or spina bifida occulta | | Cases | Ctrls | Total
Whiteman, Murphy, Hey, et al. 2000 #6510 | | | Definition(s) of outcome(s): NTD = anencephaly, encephalocele, spina bifida aperta, or spina bifida occulta | Yes | 14 | 15 | 29
Whiteman, Murphy, Hey, et al. 2000 #6510 | | | Definition(s) of outcome(s): NTD = anencephaly, encephalocele, spina bifida aperta, or spina bifida occulta | No | 680 | 679 | 1359
Whiteman, Murphy, Hey, et al. 2000 #6510 | | | Definition(s) of outcome(s): NTD = anencephaly, encephalocele, spina bifida aperta, or spina bifida occulta | Total | 694 | 694 | 1388
Whiteman, Murphy, Hey, et al. 2000 #6510 | | | Definition(s) of outcome(s): NTD = anencephaly, encephalocele, spina bifida aperta, or spina bifida occulta | | Value | Lower 95% CI | Upper 95% CI
Whiteman, Murphy, Hey, et al. 2000 #6510 | | | Definition(s) of outcome(s): NTD = anencephaly, encephalocele, spina bifida aperta, or spina bifida occulta | Odds rat | 0.93 | 0.45 | 1.95
Whiteman, Murphy, Hey, et al. 2000 #6510 | | | Definition(s) of outcome(s): NTD = anencephaly, encephalocele, spina bifida aperta, or spina bifida occulta | 2) Clomid treatment this pregnancy:
Whiteman, Murphy, Hey, et al. 2000 #6510 | | | Definition(s) of outcome(s): NTD = anencephaly, encephalocele, spina bifida aperta, or spina bifida occulta | | Cases | Ctrls | Total
Whiteman, Murphy, Hey, et al. 2000 #6510 | | | Definition(s) of outcome(s): NTD = anencephaly, encephalocele, spina bifida aperta, or spina bifida occulta | Yes | 13 | 13 | 26
Whiteman, Murphy, Hey, et al. 2000 #6510 | | | Definition(s) of outcome(s): NTD = anencephaly, encephalocele, spina bifida aperta, or spina bifida occulta | No | 681 | 681 | 1362
Whiteman, Murphy, Hey, et al. 2000 #6510 | | | Definition(s) of outcome(s): NTD = anencephaly, encephalocele, spina bifida aperta, or spina bifida occulta | Total | 694 | 694 | 1388
Whiteman, Murphy, Hey, et al. 2000 #6510 | | | Definition(s) of outcome(s): NTD = anencephaly, encephalocele, spina bifida aperta, or spina bifida occulta | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 1.00 | 0.46 | 2.17
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | Age: Mean (SD): 32.7 (4.7) Range: 19.2–47.1 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 12% Endometriosis: 9% Male factor: 50% Tubal factor: 23% PCOS: 10% Other: 15% Inclusion criteria: Those embryo transfer cycles who had at least one hCG measurement done on day 16 (+/- 1 day) Exclusion criteria: Cycles in which menstruation occurred before day 16, no hCG measurement | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | 1) EPL by mode of conception - ICSI vs IVF: | | | | Comments: No mention of number of embryos transferred Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: - Use of validated method for genomic test: n/a Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | | EPL + | EPL -
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | ICSI | 88 | 510 | 598
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | IVF | 96 | 405 | 501
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | | 184 | 915 | 1099
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | | | Lower 95% CI | Upper 95 % CI
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | Rel risk | 0.77 | 0.59 | 1.00
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | 2) EPL by mode of conception - ICSI vs GIFT:
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | | EPL+ | EPL- | Total
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | ICSI | 88 | 510 | 598
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | GIFT | 11 | 86 | 97
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | Total | 99 | 596 | 695
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | | Value | Lower 95% CI | Upper 95% CI
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | Rel risk | 1.30 | 0.72 | 2.34
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | 3) EPL by mode of conception - IVF vs GIFT:
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | | EPL+ | EPL -
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | GIFT | 11 | 86 | 97
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | IVF | 96 | 405 | 501
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | | 107 | 491 | 598
Winter, Wang, Davies, et al., 2002 #460 | Geographical location: Woodville, Australia Study dates: 1994-99 Size of population: 1196 pregnancies Study type: Cohort (retrospective) | | Definition(s) of outcome(s): Early pregnancy loss (EPL) = pregnancy loss that occurred before 6–7 weeks gestation | | | Lower 95% CI | Upper 95 % CI
Rel risk | 0.59 | 0.33 | 1.06
Wojdemann, Larsen Shalmi, et al., 2001 #4440 | Geographical location: Copenhagen, Denmark Study dates: Mar 1998 – Oct 1999 Size of population: 3026 spontaneously conceived 47 IVF 63 OI Study type: Cohort | Age: Mean (SD): Ctrls 29.1 IVF 34.4 OI 30.3 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Singletons from ongoing prospective study Exclusion criteria: Known chromosomal disorders, malformations | Definition(s) of outcome(s): PAPP-A, free-beta hCG, NT transformed into gestational age-independent MoM values | No differences between marker MoM's in IVF and OI grps compared with spontaneously conceived Screen positive (1:400) rates were 4.7% in IVF grp, 4.9% in spontaneous, 5.1% in OI grp (no diff) | | | | Comment:; - Small numbers in ART grps; - No postnatal f/u to determine actual performance of test; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for genomic test: n/a Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Woldringh, Frunt, Kremer, et al., 2005 #56680 | Geographical location: Nijmegen, The Netherlands Study dates: Oct 1994–Apr 2004 Size of population (no. of patients): 123 Study type: Case-control | Age: Mean (SD): 33.6 Race/ethnicity (n [%]): NR Diagnoses (n [%]): Unexplained infertility: 18% Endometriosis: 10% Male factor: 60% Tubal factor: 8% Cervical: 3% Inclusion criteria:; - IVF or ICSI with resulting pregnancy; - Preeclampsia reported by patient, verified by records; - Controls matched for number of fetuses, parity, maternal age at the time of delivery, pre-pregnant BMI (kg/m^2^), race and smoking.; Exclusion criteria:; - Frozen embryos; - No live birth | Definition(s) of outcome(s): Preeclampsia: gestational hypertension (repeated blood pressure measurements of > 140 mm Hg systolic or > 90 mm Hg diastolic) and proteinuria (urine protein creatinine ratio of ≥ 0.3 g/10 mmol or dipstick test ≥ 1+ for protein) after 20 weeks of gestation | 1) FSH requirements significantly higher, response significantly worse in cases than in controls. | | | | Comments: None Quality assessment: Valid ascertainment of cases:+ Unbiased selection of cases: - Appropriateness of the control population: + Comparability of cases and controls with respect to potential confounders: + Appropriateness of statistical analyses: +
Wright, Schieve, Vahratian, et al. 2004 #11600 | Geographical location: U.S. population-based sample/registry Study dates: 1999 - 2000 Size of population: 39,198 ART pregnancies 226 monozygotic (MZ) pregnancies 23,880 singletons 15,092 multiples Study type: Case-control | Age: Range: 20–44 Stratified Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Cases (MZ twins) = #fetal hearts on u/s > # embryos transferred Controls other singletons & multiples Exclusion criteria: NR | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Reference grp = day 3 ET | | | | Comments: None Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Comparability of cases and controls with respect to potential confounders: +/- Appropriateness of statistical analyses: +
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | 1) Day 2 ET:
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | MZ+ cases | singleton ctrls | Total
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 2 ET | 4 | 1345 | 1349
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 3 ET | 98 | 16774 | 16872
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Total | 102 | 18119 | 18221
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | Value | Lower 95% CI | Upper 95% CI
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Odds rat | 0.51 | 0.19 | 1.39
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | MZ+ cases | other multiples ctrls | Total
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 2 ET | 4 | 859 | 863
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 3 ET | 98 | 10590 | 10688
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Total | 102 | 11449 | 11551
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | Value | Lower 95% CI | Upper 95% CI
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Odds rat | 0.50 | 0.18 | 1.37
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | 2) Day 4 ET:
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | MZ+ cases | singleton ctrls | Total
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 4 ET | 4 | 595 | 599
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 3 ET | 98 | 16774 | 16872
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Total | 102 | 17369 | 17471
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | Value | Lower 95% CI | Upper 95% CI
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Odds rat | 1.15 | 0.42 | 3.14
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | MZ+ cases | other multiples ctrls | Total
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 4 ET | 4 | 347 | 351
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 3 ET | 98 | 10590 | 10688
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Total | 102 | 10937 | 11039
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | Value | Lower 95% CI | Upper 95% CI
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Odds rat | 1.25 | 0.46 | 3.40
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | 3) Day 5 ET:
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | MZ+ cases | singleton ctrls | Total
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 5 ET | 110 | 4451 | 4561
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 3 ET | 98 | 16774 | 16872
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Total | 208 | 21225 | 21433
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | Value | Lower 95% CI | Upper 95% CI
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Odds rat | 4.23 | 3.22 | 5.56
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | MZ+ cases | other multiples ctrls | Total
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 5 ET | 110 | 2972 | 3082
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 3 ET | 98 | 10590 | 10688
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Total | 208 | 13562 | 13770
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | Value | Lower 95% CI | Upper 95% CI
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Odds rat | 4.00 | 3.04 | 5.27
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | 4) Day 6 ET:
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | MZ+ cases | singleton ctrls | Total
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 6 ET | 10 | 715 | 725
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 3 ET | 98 | 16774 | 16872
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Total | 108 | 17489 | 17597
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | Value | Lower 95% CI | Upper 95% CI
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Odds rat | 2.39 | 1.24 | 4.61
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | MZ+ cases | other multiples ctrls | Total
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 6 ET | 10 | 324 | 334
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | DAY 3 ET | 98 | 10590 | 10688
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | Total | 108 | 10914 | 11022
Wright, Schieve, Vahratian, et al. 2004 #11600 | | | Definition(s) of outcome(s): Exposure of interest = day of embryo transfer (ET) Outcome = monozygotic (MZ) twinning | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 3.34 | 1.72 | 6.45
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | Age: Mean (SD): Median: Range: Cases: 78% <35; controls: 16% < 35 Race/ethnicity (n [%]): Cases 67% white vs 53% controls Diagnoses (n [%]): NR Inclusion criteria: Cases:; - Singleton; - ≥36 weeks; - Physician-confirmed diagnosis; Controls:; - Same criteria, except no diagnosis of spinal cord abnormalities, cerebral palsy (ICD9-CM, 1999; 343.0–343.9, 342.1, 342.8, 342.9, 344.0, 344.1, 344.30–344.32, and 344.5), genetic disease (ICD9-CM 237.7x, 277.2, 277.5, 333.6, 755.55, 759.5, 759.81), chromosomal abnormalities (ICD9-CM 758.x), arthrogryposis (ICD9-CM 754.59), ormuscle disease (ICD9-CM 335.x, 358.x, 359.x ).; Exclusion criteria: physician diagnosis of cerebral palsy (ICD9-CM, 1999; 343.0–343.9, 342.1, 342.8, 342.9, 344.0, 344.1, 344.30–344.32, and 344.5), genetic disease (ICD9-CM 237.7x, 277.2, 277.5, 333.6, 755.55, 759.5, 759.81), chromosomal abnormalities (ICD9-CM 758.x), arthrogryposis (ICD9-CM 754.59), or muscle disease (ICD9-CM 335.x, 358.x, 359.x ). | Definition(s) of outcome(s): Spinal neural tube defect, defined as spinal anomaly resulting from a defect in neurulation including spina bifida cystica (myelomeningocele or meningocele) and spina bifida occulta (intraspinal lipoma with tethered cord or dermal sinus tract) | 1) History of infertility: | | | | Comments:; - No multivariate analysis due to small # of cases; - Maternal BMI not analyzed; - 3/4 case mothers with dx of ovulatory infertility—prevalence in controls not reported; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Comparability of cases and controls with respect to potential confounders: - Appropriateness of statistical analyses: +
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | | Out + | Out - | Total
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | Infertility | 4 | 14 | 18
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | No infertility | 96 | 1512 | 1608
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | Total | 100 | 1526 | 1626
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | | Value | Lower 95% CI | Upper 95% CI
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | Odds rat | 4.50 | 1.45 | 13.93
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | 2) Infertility treatment:
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | | Out + | Out - | Total
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | Infert Rx | 4 | 14 | 18
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | No Rx | 48 | 1560 | 1608
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | Total | 52 | 1574 | 1626
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | | Value | Lower 95% CI | Upper 95% CI
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | Odds rat | 9.29 | 2.95 | 29.26
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | 3) Periconceptional clomiphene:
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | | Out + | Out - | Total
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | Clomiphene | 3 | 15 | 18
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | No CC | 32 | 1576 | 1608
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | Total | 35 | 1591 | 1626
Wu, Croen, Henning, et al., 2006 #56750 | Geographical location: Northern California Study dates: Jan 1994–Dec 1997 Size of population (no. of patients): 18 cases, 1608 controls Study type: Case-control | | | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 9.85 | 2.72 | 35.71
Yokoyama, 2003 #16870 | Geographical location: Kyoto, Japan Study dates: June 1998–Dec 1999 Size of population (no. of patients): 990 (359 infertility patients (76 ART, rest superovulation / AIH / Other), 631 spontaneous Study type: Cohort | Age: Mean (SD): Infertility: 32.7 (3.8) Control: 31.3 (4.0) Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Mothers of multiples, identified through registry, newspaper advertisements, clinical practices Exclusion criteria: NR | Definition(s) of outcome(s): Mailed questionnaire for symptoms; pregnancy/birth/pediatric data from medical records Lack of sleep: 5-point Likert scale Fatigue: Previously published fatigue scale Depressive symptoms: Yes/no response to DSM-III symptoms | 1) Presence of depressive symptoms: | | | | Comments:; - Questionnaire completed approximately 2 years after delivery; - Higher order multiples significantly more common in infertility group (37.3% vs 4.4%); - Infants with disability more common in infertility group (at least one: 15.7% vs 8.4%); - Unclear extent of potential bias in recruitment; Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Yokoyama, 2003 #16870 | | | | | Depress Sx + | Depress Sx - | Total
Yokoyama, 2003 #16870 | | | | Infertility | 56 | 303 | 359
Yokoyama, 2003 #16870 | | | | Spontaneous | 66 | 565 | 631
Yokoyama, 2003 #16870 | | | | Total | 122 | 868 | 990
Yokoyama, 2003 #16870 | | | | | Value | Lower 95% CI | Upper 95% CI
Yokoyama, 2003 #16870 | | | | Rel risk | 1.49 | 1.07 | 2.08
2) In multivariate analysis, at least one disabled child (OR 2.27 [95% CI 1.05, 5.04]) and lack of method for alleviating stress (OR 2.4 (1.3, 4.6) only significant predictors of depressive symptoms.
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | Geographical location: Szeged, Hungary Study dates: Jan 1995–Feb 2002 Size of population: 230 IVF pregnancies, 185 singletons and 36 twins Study type: Case-control IVF pregnancies matched to spontaneous controls for age, parity, gravidity, previous obstetric outcome | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | Definition(s) of outcome(s): Examined GDM, preeclampsia, myoma, previa, malpresentation, abruption, PROM, intrauterine infection, oligohydramnios, polyhydramnios (none defined). Intrapartum: C/S, fetal distress, CPD, retained placenta, pp hemorrhage, prolonged labor, prolonged 2^nd^ stage Macrosomia = birthwt ≥ 4000 g, SGA < 10%ile for Hungarian data | No significant difference for most outcomes. More macrosomia & its effects (CPD, prolonged labor) in control singletons (but still more C/S in IVF, although not significant) | | | | Comments:; - Poorly characterized cohort & matching process.; - Groups similar for education, BMI, G/P; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: + Appropriateness of the control population: + Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: + Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | 1) Premature birth (not defined) in singletons:
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | | PTB + | PTB - | Total
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | IVF sing | 29 | 156 | 185
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | Ctrl sing | 14 | 171 | 185
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | Total | 43 | 327 | 370
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | | Value | Lower 95% CI | Upper 95% CI
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | Odds rat | 2.27 | 1.16 | 4.45
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | 2) Premature birth (not defined) in twins:
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | | PTB + | PTB - | Total
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | IVF twins | 50 | 22 | 72
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | Ctrl twins | 46 | 26 | 72
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | Total | 96 | 48 | 144
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | | Value | Lower 95% CI | Upper 95% CI
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | Odds rat | 1.28 | 0.64 | 2.57
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | 3) C/S in singletons:
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | | C/S + | C/S - | Total
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | IVF sing | 78 | 107 | 185
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | Ctrl sing | 69 | 116 | 185
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | Total | 147 | 223 | 370
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | | Value | Lower 95% CI | Upper 95% CI
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | Odds rat | 1.23 | 0.81 | 1.86
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | 4) Threatened preterm delivery (not defined) in singletons:
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | | Threat PTB + | Threat PTB - | Total
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | IVF sing | 52 | 133 | 185
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | Ctrl sing | 21 | 164 | 185
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | Total | 73 | 297 | 370
Zadori, Kozinszky, Orvos, et al., 2003 #16020 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All deliveries at university hospital in study period; cases were 230 IVF pregnancies Exclusion criteria: NR | | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 3.05 | 1.75 | 5.32
Zadori, Kozinszky, Orvos, et al. 2003 #16810 | Geographical location: Szeged, Hungary Study dates: 1/1/95 – 12/31/01 Size of population: 188 singletons, 74 twins, 39 from triplet pregnancies Study type: Other IVF-ET births matched to controls for maternal age, parity, gravidity | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Congenital malformations dx'd by same neonatologist according to ICD criteria. Dx'd 4 wks after delivery National average of major birth defects in Hungary 2.2% | 1) Major malformations in singletons: | | | | Comments:; - Short followup; - Did not include pregnancies terminated bc of anomalies, but authors state this would not have changed results.; - Unclear where this population comes from, or where controls drawn from.; - “Short communication”; Quality assessment: Valid ascertainment of cases: + Unbiased selection of cases: - Appropriateness of the control population: - Verification that the control is free of cancer: NR Comparability of cases and controls with respect to potential confounders: - Validated dietary assessment method: NR Appropriateness of statistical analyses: +
Zadori, Kozinszky, Orvos, et al. 2003 #16810 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Congenital malformations dx'd by same neonatologist according to ICD criteria. Dx'd 4 wks after delivery National average of major birth defects in Hungary 2.2% | | Maj malform | Maj malform - | Total
Zadori, Kozinszky, Orvos, et al. 2003 #16810 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Congenital malformations dx'd by same neonatologist according to ICD criteria. Dx'd 4 wks after delivery National average of major birth defects in Hungary 2.2% | IVF sing | 4 | 184 | 188
Zadori, Kozinszky, Orvos, et al. 2003 #16810 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Congenital malformations dx'd by same neonatologist according to ICD criteria. Dx'd 4 wks after delivery National average of major birth defects in Hungary 2.2% | Ctrl sing | 1 | 187 | 188
Zadori, Kozinszky, Orvos, et al. 2003 #16810 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Congenital malformations dx'd by same neonatologist according to ICD criteria. Dx'd 4 wks after delivery National average of major birth defects in Hungary 2.2% | Total | 5 | 371 | 376
Zadori, Kozinszky, Orvos, et al. 2003 #16810 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Congenital malformations dx'd by same neonatologist according to ICD criteria. Dx'd 4 wks after delivery National average of major birth defects in Hungary 2.2% | | Value | Lower 95% CI | Upper 95% CI
Zadori, Kozinszky, Orvos, et al. 2003 #16810 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Congenital malformations dx'd by same neonatologist according to ICD criteria. Dx'd 4 wks after delivery National average of major birth defects in Hungary 2.2% | Odds rat | 4.07 | 0.45 | 36.72
Zadori, Kozinszky, Orvos, et al. 2003 #16810 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Congenital malformations dx'd by same neonatologist according to ICD criteria. Dx'd 4 wks after delivery National average of major birth defects in Hungary 2.2% | 2) Major malformations in twins:
Zadori, Kozinszky, Orvos, et al. 2003 #16810 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Congenital malformations dx'd by same neonatologist according to ICD criteria. Dx'd 4 wks after delivery National average of major birth defects in Hungary 2.2% | | Maj malf + | Maj malf - | Total
Zadori, Kozinszky, Orvos, et al. 2003 #16810 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Congenital malformations dx'd by same neonatologist according to ICD criteria. Dx'd 4 wks after delivery National average of major birth defects in Hungary 2.2% | IVF twin | 1 | 73 | 74
Zadori, Kozinszky, Orvos, et al. 2003 #16810 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Congenital malformations dx'd by same neonatologist according to ICD criteria. Dx'd 4 wks after delivery National average of major birth defects in Hungary 2.2% | Ctrl twin | 2 | 72 | 74
Zadori, Kozinszky, Orvos, et al. 2003 #16810 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Congenital malformations dx'd by same neonatologist according to ICD criteria. Dx'd 4 wks after delivery National average of major birth defects in Hungary 2.2% | Total | 3 | 145 | 148
Zadori, Kozinszky, Orvos, et al. 2003 #16810 | | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: NR Exclusion criteria: NR | Definition(s) of outcome(s): Congenital malformations dx'd by same neonatologist according to ICD criteria. Dx'd 4 wks after delivery National average of major birth defects in Hungary 2.2% | | Value | Lower 95% CI | Upper 95% CI
Odds rat | 0.49 | 0.04 | 5.56
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | 1) Preterm birth: | | | | Comments: None Quality assessment:Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: - Use of validated method for ascertaining exposure: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: - Analysis (multivariate adjustments) and reporting of results: -
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | | ptb+ | ptb- | Total
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | ART | 88 | 62 | 150
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | spontaneous | 106 | 82 | 188
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | Total | 194 | 144 | 338
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | | Value | Lower 95% CI | Upper 95% CI
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | Rel risk | 1.04 | 0.87 | 1.25
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | 2) NICU admission:
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | | NICU+ | NICU- | Total
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | ART | 62 | 88 | 150
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | spontaneous | 100 | 88 | 188
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | Total | 162 | 176 | 338
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | | Value | Lower 95% CI | Upper 95% CI
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | Rel risk | 0.78 | 0.62 | 0.98
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | 3) Discordant birthweight between twins:
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | | discordant+ | discordant- | Total
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | ART | 34 | 116 | 150
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | spontaneous | 30 | 158 | 188
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | Total | 64 | 274 | 338
Zadori, Kozinszky, Orvos, et al., 2004 #42250 | Geographical location: Hungary Study dates: 1995-2001 Size of population (no. of patients): N=75 ART twins N=94 spontaneous twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twins born during study period Exclusion criteria: NR | Definition(s) of outcome(s): Birthweight discordance >=20% difference between twins NICU admission Preterm birth not defined Birthweight given as continuous means only | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.42 | 0.91 | 2.21
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | Geographical location: Al-Ain, UAE Study dates: 1/97 – 12/01 Size of population: 132 twin pregnancies (36 ART, 96 spontaneous) Study type: Cohort Retrospectively reviewed all twins born in one institution during study period, analyzed by ART vs spont. | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | Definition(s) of outcome(s): Compared mean mat age, parity, number of antenatal clinic visits, highest recorded BP, impaired glucose tolerance, threatened premature labor, GA at birth, birthweight, discordant growth, mode of delivery, perinatal M&M (none defined) | No diff in PIH/preex, GDM, birthwt, NICU admissions, stillbirth, neonatal death | | | | Comments: Retrospective collection of data, no outcomes defined. Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: - Adequate description of the cohort: - Use of validated method for genomic test: n/a Use of validated method for ascertaining clinical outcomes: - Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | 1) Preterm delivery:
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | | yes | no | Total
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | ART | 15 | 21 | 36
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | Spont | 49 | 47 | 96
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | Total | 64 | 68 | 132
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | | Value | Lower 95% CI | Upper 95% CI
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | Rel risk | 0.82 | 0.53 | 1.26
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | 2) Nonelective C/S:
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | | yes | no | Total
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | ART | 12 | 24 | 36
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | Spont | 27 | 69 | 96
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | Total | 39 | 93 | 132
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | | Value | Lower 95% CI | Upper 95% CI
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | Rel risk | 1.19 | 0.68 | 2.08
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | 3) Discordant growth:
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | | yes | no | Total
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | ART | 6 | 30 | 36
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | Spont | 14 | 82 | 96
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | Total | 20 | 112 | 132
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | | Value | Lower 95% CI | Upper 95% CI
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | Rel risk | 1.14 | 0.48 | 2.75
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | 4) Antenatal admission:
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | | yes | no | Total
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | ART | 15 | 21 | 36
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | Spont | 23 | 73 | 96
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | Total | 38 | 94 | 132
Zaib-un-Nisa, Ghazal-Aswad, and Badrinath, 2003 #16420 | | Age: Mean (SD): spont 29.2, ART 30.2 Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: All twin deliveries Exclusion criteria: Deliveries < 23wks | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 1.74 | 1.03 | 2.94
Zhu, Basso, Obel, et al., 2006 #56870 | Geographical location: Denmark Study dates: June 1997–Feb 2008 Size of population (no. of patients): 85,381 Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR: Inclusion criteria: NR Exclusion criteria:; - Spontaneous abortion; - Gestational trophoblastic disease; - Ectopic; - Unknown pregnancy outcome; - Stillbirth; - Triplets | Definition(s) of outcome(s): Congenital malformations from ICD-10 in national registry | 1) Significantly increased hazard ratios for all congenital anomalies among both infertile couples conceiving spontaneously and those receiving treatment. Only genital anomalies increased when comparing infertile couples conceiving spontaneously compared to those receiving treatment (HR for treatment 2.32, 95% CI 1.24. 4.35) | | | | Comments: Exposure ascertained by questionnaire, outcome by national registry Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort: + Use of validated method for ascertaining exposure: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period:+ Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Zhu, Basso, Obel, et al., 2006 #56870 | Geographical location: Denmark Study dates: June 1997–Feb 2008 Size of population (no. of patients): 85,381 Study type: Cohort | | Definition(s) of outcome(s): Congenital malformations from ICD-10 in national registry | 2) Hazard ratio* by time to conception:
Zhu, Basso, Obel, et al., 2006 #56870 | Geographical location: Denmark Study dates: June 1997–Feb 2008 Size of population (no. of patients): 85,381 Study type: Cohort | | Definition(s) of outcome(s): Congenital malformations from ICD-10 in national registry | Spontaneous conception
Zhu, Basso, Obel, et al., 2006 #56870 | Geographical location: Denmark Study dates: June 1997–Feb 2008 Size of population (no. of patients): 85,381 Study type: Cohort | | Definition(s) of outcome(s): Congenital malformations from ICD-10 in national registry | Time (months) | | HR | 95% CI
Zhu, Basso, Obel, et al., 2006 #56870 | Geographical location: Denmark Study dates: June 1997–Feb 2008 Size of population (no. of patients): 85,381 Study type: Cohort | | Definition(s) of outcome(s): Congenital malformations from ICD-10 in national registry | 0–2 | | 1.00 (ref)
Zhu, Basso, Obel, et al., 2006 #56870 | Geographical location: Denmark Study dates: June 1997–Feb 2008 Size of population (no. of patients): 85,381 Study type: Cohort | | Definition(s) of outcome(s): Congenital malformations from ICD-10 in national registry | 3–5 | | 1.16 | 1.06, 1.27
Zhu, Basso, Obel, et al., 2006 #56870 | Geographical location: Denmark Study dates: June 1997–Feb 2008 Size of population (no. of patients): 85,381 Study type: Cohort | | Definition(s) of outcome(s): Congenital malformations from ICD-10 in national registry | 6–12 | | 1.17 | 1.06,1.30
Zhu, Basso, Obel, et al., 2006 #56870 | Geographical location: Denmark Study dates: June 1997–Feb 2008 Size of population (no. of patients): 85,381 Study type: Cohort | | Definition(s) of outcome(s): Congenital malformations from ICD-10 in national registry | >12 | | 1.29 | 1.14,1.45
Zhu, Basso, Obel, et al., 2006 #56870 | Geographical location: Denmark Study dates: June 1997–Feb 2008 Size of population (no. of patients): 85,381 Study type: Cohort | | Definition(s) of outcome(s): Congenital malformations from ICD-10 in national registry | Infertility treatment
Zhu, Basso, Obel, et al., 2006 #56870 | Geographical location: Denmark Study dates: June 1997–Feb 2008 Size of population (no. of patients): 85,381 Study type: Cohort | | Definition(s) of outcome(s): Congenital malformations from ICD-10 in national registry | 6–12 | | 1.00 (ref)
Zhu, Basso, Obel, et al., 2006 #56870 | Geographical location: Denmark Study dates: June 1997–Feb 2008 Size of population (no. of patients): 85,381 Study type: Cohort | | Definition(s) of outcome(s): Congenital malformations from ICD-10 in national registry | >12 | | 1.34 | 0.94,1.92
*adjusted for maternal age at conception, pre-pregnancy body mass index, smoking, alcohol intake, coffee consumption, and occupational status.
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | Age: % < 30: Fertile: 57.8% Infertile, spontaneous conception: 46.1% Infertile, treatment: 34.9% Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria:; - Participation in Danish National Birth Cohort; - Singleton pregnancy; Exclusion criteria:; - Not pregnant at time of interview; - Unplanned pregnancy; - Infertility treatment not associated with this pregnancy; - Treatment other than ICSI, IUI, IVF, hormones; - Spontaneous or elective abortion, mole, ectopic; - Unknown outcome | Definition(s) of outcome(s): SGA <5^th^ percentile | 1) SGA, infertility with spontaneous conception (> 12 months to conception) vs. no infertility: | | | | Comments: Exposure by self-report Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): + Large sample size: + Adequate description of the cohort:+ Use of validated method for ascertaining exposure: - Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: +
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | | Out + | Out - | Total
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | >12 months | 345 | 5377 | 5722
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | < 12 months | 2200 | 48414 | 50614
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | Total | 2545 | 53791 | 56336
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | | Value | Lower 95% CI | Upper 95% CI
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | Rel risk | 1.39 | 1.24 | 1.55
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | 2) SGA, infertility with treatment vs. < 12 months to conception:
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | | Out + | Out - | Total
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | Exp + | 304 | 3967 | 4271
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | Exp - | 2200 | 48414 | 50614
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | Total | 2504 | 52381 | 54885
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | | Value | Lower 95% CI | Upper 95% CI
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | Rel risk | 1.64 | 1.46 | 1.84
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | 3) Adjusted for maternal age, smoking, parity:
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | > 12 months duration: 1.24 (1.10, 1.40)
Zhu, Obel, Hammer Bech, et al., 2007 #72960 | Geographical location: Denmark Study dates: 1997-2003 Size of population (no. of patients): 61,145 Study type: Cohort | | Definition(s) of outcome(s): SGA <5^th^ percentile | Infertility treatment: 1.40 (1.23, 1.60)
Results similar for all types of treatment
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | Definition(s) of outcome(s): Preterm birth < 37wks Low birthweight < 2500gm Respiratory distress syndrome Hyaline membrane disease (HMD) (diagnosed by clinical course, chest xray, blood gas and acid-base values), chronic lung disease (oxygen dependency at 28th day of life) | 1) Preterm birth: | | | | Comments: None Quality assessment: Unbiased selection of the cohort (prospective recruitment of subjects): - Large sample size: - Adequate description of the cohort: - Use of validated method for ascertaining exposure: + Use of validated method for ascertaining clinical outcomes: + Adequate follow-up period: + Completeness of follow-up: + Analysis (multivariate adjustments) and reporting of results: -
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | | ptb+ | ptb- | Total
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | ART | 24 | 8 | 32
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | spontaneous | 120 | 108 | 228
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | Total | 144 | 116 | 260
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | | Value | Lower 95% CI | Upper 95% CI
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | Rel risk | 1.43 | 1.13 | 1.80
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | 2) Low birthweight:
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | | lbwt+ | lbwt- | Total
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | ART | 24 | 8 | 32
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | spontaneous | 123 | 105 | 228
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | Total | 147 | 113 | 260
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | | Value | Lower 95% CI | Upper 95% CI
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | Rel risk | 1.39 | 1.10 | 1.76
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | 3) Respiratory distress syndrome:
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | | RDS+ | RDS- | Total
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | ART | 11 | 21 | 32
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | spontaneous | 27 | 201 | 228
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | Total | 38 | 222 | 260
Zuppa, Maragliano, Scapillati, et al., 2001 #5590 | Geographical location: Rome, Italy Study dates: 1988-1997 Size of population (no. of patients): N = 228 spontaneous twins N = 32 ART twins Study type: Cohort | Age: NR Race/ethnicity (n [%]): NR Diagnoses (n [%]): NR Inclusion criteria: Twin births Exclusion criteria: NR | | | Value | Lower 95% CI | Upper 95% CI
Rel risk | 2.90 | 1.60 | 5.27