# Appendix B: List of Excluded Studies

All excluded studies listed below were reviewed in their full-text version. Following each reference, in italics, is the reason for exclusion. “Excluded,” in this context, means “not included for data abstraction.” Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

The following list does not include articles that were excluded because they were published before 2000 (n = 906) or those considered only for Questions 1b and 1c.

## References

Aboulghar M, Evers JH, Al-Inany H. Intra-venous albumin for preventing severe ovarian hyperstimulation syndrome [Full Review]. Cochrane Database of Systematic Reviews 2002, Issue 2. Art. No.: CD001302. DOI: 10.1002/14651858.CD001302. Full Text: Exclude Q3-Review article (Cochrane).
Aboulghar MM, Aboulghar MA, Mansour RT, et al. Pregnancy rate is not improved by delaying embryo transfer from days 2 to 3. Eur J Obstet Gynecol Reprod Biol. 2003;107(2):176-9. Full Text: Exclude Q3-Not RCT. [pmid: 12648864].
Abusheikha N, Salha O, Sharma V, et al. Monozygotic twinning and IVF/ICSI treatment: a report of 11 cases and review of literature.[erratum appears in Hum Reprod Update 2000 Nov–Dec;6(6):621 Note: Abusheika N [corrected to Abusheikha N]]. Hum Reprod Update. 2000;6(4):396-403. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 10972526].
Acevedo B, Sanchez M, Gomez JL, et al. Luteinizing hormone supplementation increases pregnancy rates in gonadotropin-releasing hormone antagonist donor cycles. Fertil Steril. 2004;82(2):343-7. Full Text: Exclude Q3-Donor egg. [pmid: 15302282].
Agrawal R, Holmes J, Jacobs HS. Follicle-stimulating hormone or human menopausal gonadotropin for ovarian stimulation in in vitro fertilization cycles: a meta-analysis. Fertil Steril. 2000;73(2):338-43. Full Text: Exclude Q3-Review article. [pmid: 10685540].
Aktan E, Bozkurt K, Ozer D, et al. Effects of coasting on the outcome of intracytoplasmic sperm injection-embryo transfer cycles. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2004;44(4):298-301. Full Text: Exclude Q3-Not RCT. [pmid: 15281999].
Al-Inany H, Aboulghar M. GnRH antagonist in assisted reproduction: a Cochrane review. Hum Reprod. 2002;17(4):874-85. Full Text: Exclude Q3-Review article (Cochrane). [pmid: 11925376].
Al-Inany H, Aboulghar M, Mansour R, et al. Meta-analysis of recombinant versus urinary-derived FSH: an update. Hum Reprod. 2003;18(2):305-13. Full Text: Exclude Q3-Review article. [pmid: 12571166].
Al-Inany HG, Aboulghar M, Mansour R, et al. Recombinant versus urinary human chorionic gonadotrophin for ovulation induction in assisted conception [Full Review]. Cochrane Database of Systematic Reviews 2005, Issue 2. Art. No.: CD003719. DOI: 10.1002/14651858.CD003719.pub2. Full Text: Exclude Q3-Review article (Cochrane).
al-Mizyen E, Sabatini L, Lower AM, et al. Does pretreatment with progestogen or oral contraceptive pills in low responders followed by the GnRHa flare protocol improve the outcome of IVF-ET?. J Assist Reprod Genet. 2000;17(3):140-6. Full Text: Exclude Q3-Not RCT. [pmid: 10911573].
Alborzi S, Motazedian S, Parsanezhad ME, et al. Comparison of the effectiveness of single intrauterine insemination (IUI) versus double IUI per cycle in infertile patients. Fertil Steril. 2003;80(3):595-9. Full Text: Exclude Q2-Relevant data uninterpretable. [pmid: 12969704].
Albuquerque LE, Saconato H, Maciel MC. Depot versus daily administration of gonadotrophin releasing hormone agonist protocols for pituitary desensitization in assisted reproduction cycles [Full Review]. Cochrane Database of Systematic Reviews 2005, Issue 1. Art. No.: CD002808. DOI: 10.1002/14651858.CD002808.pub2. Full Text: Exclude Q3-Review article (Cochrane).
Ali J, Rahbar S, Burjaq H, et al. Routine laser assisted hatching results in significantly increased clincal pregnancies. J Assist Reprod Genet. 2003;20(5):177-81. Full Text: Exclude Q3-Not RCT. [pmid: 12812460].
Alikani M, Cekleniak NA, Walters E, et al. Monozygotic twinning following assisted conception: an analysis of 81 consecutive cases. Hum Reprod. 2003;18(9):1937-43. Full Text: Exclude Q2-Not RCT; Full Text: Exclude Q3-Not RCT; Full Text: Include Q4. [pmid: 12923153].
Alsunaidi M. Incidence of ectopic pregnancy after assisted reproduction treatment. Saudi Medical Journal. 2007;28(4):590-2. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 17457483].
Alvarez C, Marti-Bonmati L, Novella-Maestre E, et al. Dopamine agonist cabergoline reduces hemoconcentration and ascites in hyperstimulated women undergoing assisted reproduction. [see comment]. J Clin Endocrinol Metab. 2007;92(8):2931-7. Full Text: Exclude Q3-Donor egg. [pmid: 17456571].
Alvero R, Hearns-Stokes RM, Catherino WH, et al. The presence of blood in the transfer catheter negatively influences outcome at embryo transfer. Hum Reprod. 2003;18(9):1848-52. Full Text: Exclude Q3-Not RCT. [pmid: 12923137].
Amarin ZO. A flexible protocol for cryopreservation of pronuclear and cleavage stage embryos created by conventional in vitro fertilization and intracytoplasmic sperm injection. Eur J Obstet Gynecol Reprod Biol. 2004;117(2):189-93. Full Text: Exclude Q3-Not RCT. [pmid: 15541856].
Amarin ZO, Obeidat BR, Rouzi AA, et al. Intracytoplasmic sperm injection after total conventional in-vitro fertilization failure. Saudi Medical Journal. 2005;26(3):411-5. Full Text: Exclude Q3-Not RCT. [pmid: 15806209].
Amer SA, Banu Z, Li TC, et al. Long-term follow-up of patients with polycystic ovary syndrome after laparoscopic ovarian drilling: endocrine and ultrasonographic outcomes. Hum Reprod. 2002;17(11):2851-7. Full Text: Exclude Q2-Not RCT. [pmid: 12407038].
Amer SA, Li TC, Ledger WL. Ovulation induction using laparoscopic ovarian drilling in women with polycystic ovarian syndrome: predictors of success. Hum Reprod. 2004;19(8):1719-24. Full Text: Exclude Q3-Not RCT. [pmid: 15178663].
American College of Obstetricians and Gynecologists. Diagnosis and management of preeclampsia. Practice Bulletin No. 33. American College of Obstetricians and Gynecologists: Washington, DC; January 2002. Full Text: Exclude Q4-Background article.
American College of Obstetricians and Gynecologists. Screening for fetal chromosomal abnormalities. Practice Bulletin No. 77. American College of Obstetricians and Gynecologists: Washington, DC; January 2007. Full Text: Exclude Q4-Background article.
Anderheim L, Holter H, Bergh C, et al. Extended encounters with midwives at the first IVF cycle: a controlled trial. Reproductive Biomedicine Online. 2007;14(3):279-87. Full Text: Exclude Q3-Not RCT. [pmid: 17359577].
Andersen AN, Gianaroli L, Felberbaum R, et al. Assisted reproductive technology in Europe, 2001. Results generated from European registers by ESHRE. Hum Reprod. 2005;20(5):1158-76. Full Text: Exclude Q4-Data not per patient. [pmid: 15665021].
Andersen CY, Westergaard LG, van Wely M. FSH isoform composition of commercial gonadotrophin preparations: a neglected aspect?. Reproductive Biomedicine Online. 2004;9(2):231-6. Full Text: Exclude Q3-Review article. [pmid: 15333258].
Anderson AR, Wiemer KE, Weikert ML, et al. Fertilization, embryonic development and pregnancy losses with intracytoplasmic sperm injection for surgically-retrieved spermatozoa. Reproductive Biomedicine Online. 2002;5(2):142-7. Full Text: Exclude Q3-Not RCT. [pmid: 12419038].
Anderson AR, Wilkinson SS, Price S, et al. Reduction of high order multiples in frozen embryo transfers. Reproductive Biomedicine Online. 2005;10(3):402-5. Full Text: Exclude Q3-Not RCT. [pmid: 15820053].
Anderson KM, Sharpe M, Rattray A, et al. Distress and concerns in couples referred to a specialist infertility clinic. J Psychosom Res. 2003;54(4):353-5. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 12670613].
Angelini A, Brusco GF, Barnocchi N, et al. Impact of physician performing embryo transfer on pregnancy rates in an assisted reproductive program. J Assist Reprod Genet. 2006;23(78):329-32. Full Text: Exclude Q3-Not RCT. [pmid: 16983520].
Anger JT, Wang GJ, Boorjian SA, et al. Sperm cryopreservation and in vitro fertilization/intracytoplasmic sperm injection in men with congenital bilateral absence of the vas deferens: a success story. Fertil Steril. 2004;82(5):1452-4. Full Text: Exclude Q3-Not RCT. [pmid: 15533379].
Anonymous. Contribution of assisted reproductive technology and ovulation-inducing drugs to triplet and higher-order multiple births—United States, 1980-1997. Morb Mortal Wkly Rep Surveill Summ 2000;49(24):535–8. Full Text: Exclude Q4-Background article.
Antinori S, Gholami GH, Versaci C, et al. Obstetric and prenatal outcome in menopausal women: a 12-year clinical study. Reproductive Biomedicine Online. 2003;6(2):257-61. Full Text: Exclude Q4-F age > 45. [pmid: 12676011].
Antman AM, Politch JA, Ginsburg ES. Conversion of high-response gonadotropin intrauterine insemination cycles to in vitro fertilization results in excellent ongoing pregnancy rates. Fertil Steril. 2002;77(4):715-20. Full Text: Exclude Q3-Not RCT. [pmid: 11937122].
Aoki VW, Wilcox AL, Peterson CM, et al. Comparison of four media types during 3-day human IVF embryo culture. Reproductive Biomedicine Online. 2005;10(5):600-6. Full Text: Exclude Q3-Not RCT. [pmid: 15949217].
Aoki VW, Wilcox AL, Thorp C, et al. Improved in vitro fertilization embryo quality and pregnancy rates with intracytoplasmic sperm injection of sperm from fresh testicular biopsy samples vs. frozen biopsy samples. Fertil Steril. 2004;82(6):1532-5. Full Text: Exclude Q3-Not RCT. [pmid: 15589855].
Artini PG, Valentino V, Cela V, et al. A randomized control comparison study of culture media (HTF versus P1) for human in vitro fertilization. Eur J Obstet Gynecol Reprod Biol. 2004;116(2):196-200. Full Text: Exclude Q3-Method of allocation to treatment unclear. [pmid: 15358464].
Aruna J, Mittal S, Kumar S, et al. Metformin therapy in women with polycystic ovary syndrome. Int J Gynaecol Obstet. 2004;87(3):237-41. Full Text: Exclude Q2-Not RCT. [pmid: 15548396].
Ashkenazi J, Yoeli R, Orvieto R, et al. Double (consecutive) transfer of early embryos and blastocysts: aims and results. Fertil Steril. 2000;74(5):936-40. Full Text: Exclude Q3-Not RCT. [pmid: 11056236].
Aslan D, Elizur SE, Levron J, et al. Comparison of zygote intrafallopian tube transfer and transcervical uterine embryo transfer in patients with repeated implantation failure. Eur J Obstet Gynecol Reprod Biol. 2005;122(2):191-4. Full Text: Exclude Q3-Not RCT. [pmid: 15950368].
Athaullah N, Proctor M, Johnson NP. Oral versus injectable ovulation induction agents for unexplained subfertility [Full Review]. Cochrane Database of Systematic Reviews 2002, Issue 3. Art. No.: CD003052. DOI: 10.1002/14651858.CD003052. Full Text: Exclude Q2-Review article (Cochrane).
Ayustawati, Shibahara H, Hirano Y, et al. Serum leptin concentrations in patients with severe ovarian hyperstimulation syndrome during in vitro fertilization-embryo transfer treatment. Fertil Steril. 2004;82(3):579-85. Full Text: Exclude Q3-No pregnancy outcome. [pmid: 15374699].
Azziz R, Ehrmann D, Legro RS, et al. Troglitazone improves ovulation and hirsutism in the polycystic ovary syndrome: a multicenter, double blind, placebo-controlled trial. J Clin Endocrinol Metab. 2001;86(4):1626-32. Full Text: Exclude Q2-Drug no longer on market. [pmid: 11297595].
Baba K, Ishihara O, Hayashi N, et al. Three-dimensional ultrasound in embryo transfer. Ultrasound Obstet Gynecol. 2000;16(4):372-3. Full Text: Exclude Q3-Not RCT. [pmid: 11169315].
Bahceci M, Ciray HN, Karagenc L, et al. Effect of oxygen concentration during the incubation of embryos of women undergoing ICSI and embryo transfer: a prospective randomized study. Reproductive Biomedicine Online. 2005;11(4):438-43. Full Text: Exclude Q3-Not RCT. [pmid: 16274603].
Bahceci M, Ulug U. Does underlying infertility aetiology impact on first trimester miscarriage rate following ICSI? A preliminary report from 1244 singleton gestations. Hum Reprod. 2005;20(3):717-21. Full Text: Exclude Q4-No pregnancy outcome. [pmid: 15608032].
Balaban B, Lundin K, Morrell JM, et al. An alternative to PVP for slowing sperm prior to ICSI. Hum Reprod. 2003;18(9):1887-9. Full Text: Exclude Q3-Not RCT. [pmid: 12923144].
Balaban B, Urman B, Alatas C, et al. Blastocyst-stage transfer of poor-quality cleavage-stage embryos results in higher implantation rates. Fertil Steril. 2001;75(3):514-8. Full Text: Exclude Q3-Not RCT. [pmid: 11239534].
Balaban B, Urman B, Alatas C, et al. A comparison of four different techniques of assisted hatching. Hum Reprod. 2002;17(5):1239-43. Full Text: Exclude Q3-Not RCT. [pmid: 11980745].
Balaban B, Urman B, Isiklar A, et al. Blastocyst transfer following intracytoplasmic injection of ejaculated, epididymal or testicular spermatozoa. Hum Reprod. 2001;16(1):125-9. Full Text: Exclude Q3-Not RCT. [pmid: 11139550].
Balaban B, Yakin K, Urman B. Randomized comparison of two different blastocyst grading systems. Fertil Steril. 2006;85(3):559-63. Full Text: Exclude Q3-Not RCT. [pmid: 16500319].
Balasch J, Fabregues F, Creus M, et al. Follicular development and hormonal levels following highly purified or recombinant follicle-stimulating hormone administration in ovulatory women undergoing ovarian stimulation after pituitary suppression for in vitro fertilization: implications for implantation potential. J Assist Reprod Genet. 2000;17(1):20-7. Full Text: Exclude Q3-Not RCT. [pmid: 10754779].
Balasch J, Fabregues F, Penarrubia J, et al. Outcome from consecutive assisted reproduction cycles in patients treated with recombinant follitropin alfa filled-by-bioassay and those treated with recombinant follitropin alfa filled-by-mass. Reproductive Biomedicine Online. 2004;8(4):408-13. Full Text: Exclude Q3-Not RCT. [pmid: 15149563].
Baor L, Bar-David J, Blickstein I. Psychosocial resource depletion of parents of twins after assisted versus spontaneous reproduction. International Journal of Fertility & Womens Medicine. 2004;49(1):13-8. Full Text: Exclude Q4-N < 100 (not RCT).
Bar-Hava I, Kerner R, Yoeli R, et al. Immediate ambulation after embryo transfer: a prospective study. Fertil Steril. 2005;83(3):594-7. Full Text: Exclude Q3-Not RCT. [pmid: 15749486].
Barlow DH. The design, publication and interpretation of research in Subfertility Medicine: uncomfortable issues and challenges to be faced. Hum Reprod. 2003;18(5):899-901. Full Text: Exclude Q2-Background article. [pmid: 12721158].
Barrenetxea G, Lopez de Larruzea A, Ganzabal T, et al. Blastocyst culture after repeated failure of cleavage-stage embryo transfers: a comparison of day 5 and day 6 transfers. Fertil Steril. 2005;83(1):49-53. Full Text: Exclude Q3-Not RCT. [pmid: 15652886].
Barroso G, Menocal G, Felix H, et al. Comparison of the efficacy of the aromatase inhibitor letrozole and clomiphene citrate as adjuvants to recombinant follicle-stimulating hormone in controlled ovarian hyperstimulation: a prospective, randomized, blinded clinical trial. Fertil Steril. 2006;86(5):1428-31. Full Text: Exclude Q2-Not RCT. [pmid: 16978619].
Bartoov B, Berkovitz A, Eltes F, et al. Pregnancy rates are higher with intracytoplasmic morphologically selected sperm injection than with conventional intracytoplasmic injection. Fertil Steril. 2003;80(6):1413-9. Full Text: Exclude Q3-Not RCT. [pmid: 14667877].
Baruffi RL, Mauri AL, Petersen CG, et al. Recombinant LH supplementation to recombinant FSH during induced ovarian stimulation in the GnRH-antagonist protocol: a meta-analysis. Reproductive Biomedicine Online. 2007;14(1):14-25. Full Text: Exclude Q3-Review article. [pmid: 17207326].
Baukloh V. German Society for Human Reproductive Biology. Retrospective multicentre study on mechanical and enzymatic preparation of fresh and cryopreserved testicular biopsies. Hum Reprod. 2002;17(7):1788-94. Full Text: Exclude Q3-Not RCT. [pmid: 12093841].
Bauman R, Vujisic S, Tripalo A, et al. Influence of hormonal stimulation on in vitro fertilization/embryo transfer outcome. Eur J Obstet Gynecol Reprod Biol. 2005;119(1):94-102. Full Text: Exclude Q3-Not RCT. [pmid: 15734092].
Bayram N, van Wely M, van der Veen F. Pulsatile gonadotrophin releasing hormone for ovulation induction in subfertility associated with polycystic ovary syndrome [Full Review]. Cochrane Database of Systematic Reviews 2003, Issue 3. Art. No.: CD000412. DOI: 10.1002/14651858.CD000412.pub2. Full Text: Exclude Q2-Review article (Cochrane).
Bayram N, van Wely M, van der Veen F. Recombinant FSH versus urinary gonadotrophins or recombinant FSH for ovulation induction in subfertility associated with polycystic ovary syndrome [Full Review]. Cochrane Database of Systematic Reviews 2001, Issue 2. Art. No.: CD002121. DOI: 10.1002/14651858.CD002121. Full Text: Exclude Q2-Review article (Cochrane).
Beck JI, Boothroyd C, Proctor M, et al. Oral anti-oestrogens and medical adjuncts for subfertility associated with anovulation [Full Review]. Cochrane Database of Systematic Reviews 2005, Issue 1. Art. No.: CD002249. DOI: 10.1002/14651858.CD002249.pub3. Full Text: Exclude Q2-Review article (Cochrane).
Behr B, Fisch JD, Racowsky C, et al. Blastocyst-ET and monozygotic twinning. J Assist Reprod Genet. 2000;17(6):349-51. Full Text: Exclude Q3-Not RCT. [pmid: 11042833].
Beloosesky R, Kol S, Lightman A, et al. Ovarian stimulation in in vitro fertilization with or without the “long” gonadotropin-releasing hormone agonist protocol: effect on cycle duration and outcome. Fertil Steril. 2000;74(1):166-8. Full Text: Exclude Q3-Not RCT. [pmid: 10899516].
Ben-Chetrit A, Eldar-Geva T, Gal M, et al. The questionable use of albumin for the prevention of ovarian hyperstimulation syndrome in an IVF programme: a randomized placebo-controlled trial. Hum Reprod. 2001;16(9):1880-4. Full Text: Exclude Q2-Not RCT; Full Text: Exclude Q3-Not RCT. [pmid: 11527892].
Ben Rhouma K, Marrakchi H, Khouja H, et al. Outcome of intracytoplasmic injection of fresh and frozen-thawed testicular spermatozoa. A comparative study. J Reprod Med. 2003;48(5):349-54. Full Text: Exclude Q3-Not RCT. [pmid: 12815908].
Ben-Shlomo I, Geslevich J, Shalev E. Can we abandon routine evaluation of serum estradiol levels during controlled ovarian hyperstimulation for assisted reproduction?. Fertil Steril. 2001;76(2):300-3. Full Text: Exclude Q3-Not RCT. [pmid: 11476776].
Bensdorp AJ, Cohlen BJ, Heineman MJ, et al. Intra-uterine insemination for male subfertility [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 4. Art. No.: CD000360. DOI: 10.1002/14651858.CD000360.pub4. Full Text: Exclude Q2-Review article (Cochrane).
Berkkanoglu M, Isikoglu M, Aydin D, et al. Clinical effects of ovulation induction with recombinant follicle-stimulating hormone supplemented with recombinant luteinizing hormone or low-dose recombinant human chorionic gonadotropin in the midfollicular phase in microdose cycles in poor responders. Fertil Steril. 2007;88(3):665-9. Full Text: Exclude Q3-Data not per patient. [pmid: 17292895].
Berkovitz A, Eltes F, Lederman H, et al. How to improve IVF-ICSI outcome by sperm selection. Reproductive Biomedicine Online. 2006;12(5):634-8. Full Text: Exclude Q3-Not RCT. [pmid: 16790113].
Berry RJ, Kihlberg R, Devine O. Impact of misclassification of in vitro fertilisation in studies of folic acid and twinning: modelling using population based Swedish vital records. BMJ. 2005;330(7495):815. Full Text: Exclude-Not relevant to any question. [pmid: 15722370]. [pmcid: 556070].
Biacchiardi CP, Revelli A, Gennarelli G, et al. Fallopian tube sperm perfusion versus intrauterine insemination in unexplained infertility: a randomized, prospective, cross-over trial. Fertil Steril. 2004;81(2):448-51. Full Text: Exclude Q2-Biased study design. [pmid: 14967388].
Bjercke S, Fedorcsak P, Abyholm T, et al. IVF/ICSI outcome and serum LH concentration on day 1 of ovarian stimulation with recombinant FSH under pituitary suppression. Hum Reprod. 2005;20(9):2441-7. Full Text: Exclude Q3-Not RCT. [pmid: 15919773].
Blake DA, Farquhar CM, Johnson N, et al. Cleavage stage versus blastocyst stage embryo transfer in assisted conception [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 4. Art. No.: CD002118. DOI: 10.1002/14651858.CD002118.pub3. Full Text: Exclude Q3-Review article (Cochrane).
Blickstein I. Estimation of iatrogenic monozygotic twinning rate following assisted reproduction: Pitfalls and caveats. Am J Obstet Gynecol. 2005;192(2):365-8. Full Text: Exclude Q4 -No relevant data. [pmid: 15695973].
Bodri D, Vernaeve V, Guillen JJ, et al. Comparison between a GnRH antagonist and a GnRH agonist flare-up protocol in oocyte donors: a randomized clinical trial. Hum Reprod. 2006;21(9):2246-51. Full Text: Exclude Q3-Donor egg. [pmid: 16704995].
Bolton P, Yamashita Y, Farquhar CM. Role of fertility treatments in multiple pregnancy at National Women's Hospital from 1996 to 2001. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2003;43(5):364-8. Full Text: Exclude Q2-Not RCT. [pmid: 14717313].
Boomsma CM, Heineman MJ, Cohlen BJ, et al. Semen preparation techniques for intrauterine insemination [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 4. Art. No.: CD004507. DOI: 10.1002/14651858.CD004507.pub3. Full Text: Exclude Q2-Review article (Cochrane).
Boomsma CM, Keay SD, Macklon NS. Peri-implantation glucocorticoid administration for assisted reproductive technology cycles [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 1. Art. No.: CD005996. DOI: 10.1002/14651858.CD005996.pub2. Full Text: Exclude Q3-Review article (Cochrane).
Boone WR, Crane MM 4th, Johnson JE, et al. Changes in the freezing protocol for human zygotes alter embryonic development and pregnancy rates. Fertil Steril. 2005;83(1):182-8. Full Text: Exclude Q3-Not RCT. [pmid: 15652905].
Borges E Jr, Rossi-Ferragut LM, Pasqualotto FF, et al. Testicular sperm results in elevated miscarriage rates compared to epididymal sperm in azoospermic patients. Sao Paulo Med J. 2002;120(4):122-6. Full Text: Exclude Q3-Not RCT. [pmid: 12436160].
Borini A, Dal Prato L, Bianchi L, et al. Effect of duration of estradiol replacement on the outcome of oocyte donation. J Assist Reprod Genet. 2001;18(4):185-90. Full Text: Exclude Q3-Not RCT. [pmid: 11432108].
Brinton L. Long-term effects of ovulation-stimulating drugs on cancer risk. Reproductive Biomedicine Online. 2007;15(1):38-44. Full Text: Exclude Q4-Background article. [pmid: 17623533].
Brinton LA, Lamb EJ, Moghissi KS, et al. Ovarian cancer risk after the use of ovulation-stimulating drugs. Obstet Gynecol. 2004;103(6):1194-203. Full Text: Exclude Q2-Not RCT; Full Text: Include Q4. [pmid: 15172852].
Brinton LA, Lamb EJ, Moghissi KS, et al. Ovarian cancer risk associated with varying causes of infertility. Fertil Steril. 2004;82(2):405-14. Full Text: Exclude Q2-Not RCT; Full Text: Include Q4. [pmid: 15302291].
Brinton LA, Scoccia B, Moghissi KS, et al. Breast cancer risk associated with ovulation-stimulating drugs. Hum Reprod. 2004;19(9):2005-13. Full Text: Exclude Q2-Not RCT; Full Text: Include Q4. [pmid: 15217997].
Britt DW, Risinger ST, Mans M, et al. Anxiety among women who have undergone fertility therapy and who are considering multifetal pregnancy reduction: trends and implications. Journal of Maternal-Fetal & Neonatal Medicine. 2003;13(4):271-8. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 12854930].
Brown JA, Buckingham K, Abou-Setta A, et al. Ultrasound versus ‘clinical touch’ for catheter guidance during embryo transfer in women [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 1. Art. No.: CD006107. DOI: 10.1002/14651858.CD006107.pub2. Full Text: Exclude Q3-Review article (Cochrane).
Brown SE, Toner JP, Schnorr JA, et al. Vaginal misoprostol enhances intrauterine insemination. Hum Reprod. 2001;16(1):96-101. Full Text: Exclude Q2-Data not per patient. [pmid: 11139544].
Buch B, Galan JJ, Lara M, et al. Absence of de novo Y-chromosome microdeletions in male children conceived through intracytoplasmic sperm injection. Fertil Steril. 2004;82(6):1679-80. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 15589879].
Bungum M, Bungum L, Humaidan P. A prospective study, using sibling oocytes, examining the effect of 30 seconds versus 90 minutes gamete co-incubation in IVF. Hum Reprod. 2006;21(2):518-23. Full Text: Exclude Q3-Not RCT. [pmid: 16239314].
Burkman RT, Tang MT, Malone KE, et al. Infertility drugs and the risk of breast cancer: findings from the National Institute of Child Health and Human Development Women's Contraceptive and Reproductive Experiences Study. Fertil Steril. 2003;79(4):844-51. Full Text: Exclude Q2-Not RCT; Full Text: Include Q4. [pmid: 12749419].
Callahan TL, Hall JE, Ettner SL, et al. The economic impact of multiple-gestation pregnancies and the contribution of assisted-reproduction techniques to their incidence. N Engl J Med. 1994;331(4):244-9. Full Text: Exclude Q4-Background article. [pmid: 8015572].
Cantineau AE, Cohlen BJ. Dutch IUI Study Group. The prevalence and influence of luteinizing hormone surges in stimulated cycles combined with intrauterine insemination during a prospective cohort study. Fertil Steril. 2007;88(1):107-12. Full Text: Exclude Q2-Not RCT (subgroup analysis of data from RCT. [pmid: 17445811].
Cantineau AEP, Cohlen BJ, Heineman MJ. Ovarian stimulation protocols (anti-oestrogens, gonadotrophins with and without GnRH agonists/antagonists) for intrauterine insemination (IUI) in women with subfertility [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 2. Art. No.: CD005356. DOI: 10.1002/14651858.CD005356.pub2. Full Text: Exclude Q2-Review article (Cochrane).
Cantineau AEP, Heineman MJ, Cohlen BJ. Single versus double intrauterine insemination (IUI) in stimulated cycles for subfertile couples [Full Review]. Cochrane Database of Systematic Reviews 2003, Issue 1. Art. No.: CD003854. DOI: 10.1002/14651858.CD003854. Full Text: Exclude Q2-Review article (Cochrane).
Caroppo E, Niederberger C, Vizziello GM, et al. Recombinant human follicle-stimulating hormone as a pretreatment for idiopathic oligoasthenoteratozoospermic patients undergoing intracytoplasmic sperm injection. Fertil Steril. 2003;80(6):1398-403. Full Text: Exclude Q3-Not RCT. [pmid: 14667875].
Casadei L, Zamaro V, Calcagni M, et al. Homologous intrauterine insemination in controlled ovarian hyperstimulation cycles: a comparison among three different regimens. Eur J Obstet Gynecol Reprod Biol. 2006;129(2):155-61. Full Text: Exclude-Not relevant to any question. [pmid: 16687201].
Casper RF, Mitwally MF. Review: aromatase inhibitors for ovulation induction. J Clin Endocrinol Metab. 2006;91(3):760-71. Full Text: Exclude Q2-Background article. [pmid: 16384846].
Causio F, Fischetto R, Sarcina E, et al. Chromosome analysis of spontaneous abortions after in vitro fertilization (IVF) and intracytoplasmic sperm injection (ICSI). Eur J Obstet Gynecol Reprod Biol. 2002;105(1):44-8. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 12270564].
Cedrin-Durnerin I, Bstandig B, Galey J, et al. Beneficial effects of GnRH agonist administration prior to ovarian stimulation for patients with a short follicular phase. Reproductive Biomedicine Online. 2003;7(2):179-84. Full Text: Exclude Q3-Not RCT. [pmid: 14567886].
Centers for Disease Control and Prevention, American Society for Reproductive Medicine, Society for Assisted Reproductive Technology. 2005 Assisted Reproductive Technology Success Rates: National Summary and Fertility Clinic Reports. Atlanta: Centers for Disease Control and Prevention; 2007. Available at: www.cdc.gov/ART/ART2005/index.htm. Accessed 10 January 2008. Full Text: Exclude Q2-Background article.
Cha KY, Chung HM, Lee DR, et al. Obstetric outcome of patients with polycystic ovary syndrome treated by in vitro maturation and in vitro fertilization-embryo transfer. Fertil Steril. 2005;83(5):1461-5. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 15866585].
Cha KY, Han SY, Chung HM, et al. Pregnancies and deliveries after in vitro maturation culture followed by in vitro fertilization and embryo transfer without stimulation in women with polycystic ovary syndrome. Fertil Steril. 2000;73(5):978-83. Full Text: Exclude Q3-Not RCT. [pmid: 10785224].
Chalermchockcharoenkit A, Tinneberg HR. The pregnancy rates—a retrospective comparison of tubal and uterine embryo transfers. J Med Assoc Thai. 2001;84(2):247-52. Full Text: Exclude Q3-Not RCT. [pmid: 11336085].
Chang PL, Zeitoun KM, Chan LK, et al. GnRH antagonist in older IVF patients. Retrieval rates and clinical outcome. J Reprod Med. 2002;47(4):253-8. Full Text: Exclude Q3-Not RCT. [pmid: 12012875].
Chasen ST, Luo G, Perni SC, et al. Are in vitro fertilization pregnancies with early spontaneous reduction high risk?. Am J Obstet Gynecol. 2006;195(3):814-7. Full Text: Exclude Q4-High proportion of donor egg pregnancies. [pmid: 16949417].
Check JH, Check ML, Nazari P, et al. Presence of LH in gonadotropins associated with higher IVF pregnancy rates when basal serum LH is increased. Clin Exp Obstet Gynecol. 2001;28(2):102-6. Full Text: Exclude Q3-Not RCT. [pmid: 11491366].
Check JH, Hourani W, Check ML, et al. Effect of treating antibody-coated sperm with chymotrypsin on pregnancy rates following IUI as compared to outcome of IVF/ICSI. Arch Androl. 2004;50(2):93-5. Full Text: Exclude Q3-Not RCT. [pmid: 14761839].
Check JH, Liss J, Check ML, et al. Leukocyte immunotherapy improves live delivery rates following embryo transfer in women with at least two previous failures: a retrospective review. Clin Exp Obstet Gynecol. 2005;32(2):85-8. Full Text: Exclude Q3-Data not per patient. [pmid: 16108386].
Check JH, Liss JR, Check ML, et al. Lymphocyte immunotherapy can improve pregnancy outcome following embryo transfer (ET) in patients failing to conceive after two previous ET. Clin Exp Obstet Gynecol. 2005;32(1):21-2. Full Text: Exclude Q3-Not RCT. [pmid: 15864930].
Check JH, Swenson K, Summers-Chase D, et al. Effect of transferring frozen-thawed embryos resulting from fertilization of immature oocytes matured one day in culture prior to intracytoplasmic sperm injection (ICSI) on implantation rates. Clin Exp Obstet Gynecol. 2003;30(4):197-8. Full Text: Exclude Q3-Not RCT. [pmid: 14664410].
Check M, Wilson C, Check JH, et al. Evidence that exclusive use of Follistim may produce better pregnancy results than the use of Gonal-F following in vitro fertilization (IVF) - embryo transfer (ET). Clin Exp Obstet Gynecol. 2002;29(3):183-4. Full Text: Exclude Q3-Not RCT. [pmid: 12521013].
Check ML, Check JH, Katsoff D, et al. ICSI as an effective therapy for male factor with antisperm antibodies. Arch Androl. 2000;45(3):125-30. Full Text: Exclude Q3-Not RCT. [pmid: 11111859].
Check ML, Check JH, Summers-Chase D, et al. Pregnancy/implantation rates as related to age following transfer of frozen embryos produced by ICSI. Arch Androl. 2001;47(3):161-5. Full Text: Exclude Q3-Not RCT. [pmid: 11695837].
Check ML, Kiefer D, Check JH, et al. Treatment of sperm with subnormal host scores with chymotrypsin/viable pregnancy after IUI. Arch Androl. 2002;48(2):155-8. Full Text: Exclude Q3-Not RCT. [pmid: 11868629].
Cheewadhanaraks S. Comparison of fecundity after second laparotomy for endometriosis to in vitro fertilization and embryo transfer. J Med Assoc Thai. 2004;87(4):361-6. Full Text: Exclude Q3-Not RCT. [pmid: 15217170].
Chen CD, Chao KH, Yang JH, et al. Comparison of coasting and intravenous albumin in the prevention of ovarian hyperstimulation syndrome. Fertil Steril. 2003;80(1):86-90. Full Text: Exclude Q3-Not RCT. [pmid: 12849806].
Chen SU, Chen HF, Lien YR, et al. Schedule to inject in vitro matured oocytes may increase pregnancy after intracytoplasmic sperm injection. Arch Androl. 2000;44(3):197-205. Full Text: Exclude Q3-Not RCT. [pmid: 10864367].
Cheon KW, Byun HK, Yang KM, et al. Efficacy of recombinant human follicle-stimulating hormone in improving oocyte quality in assisted reproductive techniques. J Reprod Med. 2004;49(9):733-8. Full Text: Exclude Q2-Data not per patient; Full Text: Exclude Q3-Data not per patient. [pmid: 15493565].
Cheung WM, Ng EH, Lau EY, et al. Is there any difference in pregnancy and implantation rates when nurses perform embryo transfer in an IVF-ET program?. Gynecol Obstet Invest. 2003;56(1):1-5. Full Text: Exclude Q3-Not RCT. [pmid: 12867759].
Child TJ, Abdul-Jalil AK, Gulekli B, et al. In vitro maturation and fertilization of oocytes from unstimulated normal ovaries, polycystic ovaries, and women with polycystic ovary syndrome. Fertil Steril. 2001;76(5):936-42. Full Text: Exclude Q3-Not RCT. [pmid: 11704114].
Child TJ, Phillips SJ, Abdul-Jalil AK, et al. A comparison of in vitro maturation and in vitro fertilization for women with polycystic ovaries. Obstet Gynecol. 2002;100(4):665-70. Full Text: Exclude Q3-Not RCT. [pmid: 12383531].
Choe JK, Nazari A, Check JH, et al. Marked improvement in clinical pregnancy rates following in vitro fertilization-embryo transfer seen when transfer technique and catheter were changed. Clin Exp Obstet Gynecol. 2001;28(4):223-4. Full Text: Exclude Q3-Not RCT. [pmid: 11838743].
Chou HC, Tsao PN, Yang YS, et al. Neonatal outcome of infants born after in vitro fertilization at National Taiwan University Hospital. J Formos Med Assoc. 2002;101(3):203-5. Full Text: Exclude Q4-Can't compare single vs. single, twin vs. twin by method of conception. [pmid: 12051016].
Chow JS, Benson CB, Racowsky C, et al. Frequency of a monochorionic pair in multiple gestations: relationship to mode of conception. J Ultrasound Med. 2001;20(7):757-60. quiz 761. Full Text: Exclude Q2-Not RCT; Full Text: Include Q4. [pmid: 11444734].
Chung K, Krey L, Katz J, et al. Evaluating the role of exogenous luteinizing hormone in poor responders undergoing in vitro fertilization with gonadotropin-releasing hormone antagonists. Fertil Steril. 2005;84(2):313-8. Full Text: Exclude Q3-Not RCT. [pmid: 16084870].
Claman P, Wilkie V, Collins D. Timing intrauterine insemination either 33 or 39 hours after administration of human chorionic gonadotropin yields the same pregnancy rates as after superovulation therapy. Fertil Steril. 2004;82(1):13-6. Full Text: Exclude Q2-Data not per patient. [pmid: 15236979].
Clark JH, Markaverich BM. The agonistic-antagonistic properties of clomiphene: a review. Pharmacol Ther. 1981;15(3):467-519. Full Text: Exclude Q2-Background article. [pmid: 7048350].
Cobellis L, Pecori E, De Lucia E, et al. Regression of ovarian enlargement in pharmacological ovulation induction. Gynecol Endocrinol. 2001;15(3):239-42. Full Text: Exclude-Not relevant to any question. [pmid: 11447737].
Coll O, Lopez M, Vidal R, et al. Fertility assessment in non-infertile HIV-infected women and their partners. Reproductive Biomedicine Online. 2007;14(4):488-94. Full Text: Exclude-Not relevant to any question. [pmid: 17425832].
Collins JA, Van Steirteghem A. Overall prognosis with current treatment of infertility. Hum Reprod Update. 2004;10(4):309-16. Full Text: Exclude Q3-Not RCT. [pmid: 15192058].
Combelles CM, Orasanu B, Ginsburg ES, et al. Optimum number of embryos to transfer in women more than 40 years of age undergoing treatment with assisted reproductive technologies. Fertil Steril. 2005;84(6):1637-42. Full Text: Exclude Q3-Not RCT. [pmid: 16359957].
Commenges-Ducos M, Piault S, Papaxanthos A, et al. Recombinant follicle-stimulating hormone versus human menopausal gonadotropin in the late follicular phase during ovarian hyperstimulation for in vitro fertilization. Fertil Steril. 2002;78(5):1049-54. Full Text: Exclude Q3-Not RCT. [pmid: 12413992].
Confino E, Zhang X, Kazer RR. GnRHa flare and IVF pregnancy rates. Int J Gynaecol Obstet. 2004;85(1):36-9. Full Text: Exclude Q3-Not RCT. [pmid: 15050465].
Costello MF, Emerson S, Miranda T, et al. Case series of a single centre's treatment of ovulatory infertility with clomiphene citrate and intrauterine insemination in 2002. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2004;44(2):156-9. Full Text: Exclude Q3-Not RCT. [pmid: 15089842].
Cousineau TM, Domar AD. Psychological impact of infertility. Best Pract Res Clin Obstet Gynaecol. 2007;21(2):293-308. Full Text: Exclude Q4-Background article. [pmid: 17241818].
Cousineau TM, Green TC, Corsini EA, et al. Development and validation of the Infertility Self-Efficacy scale. Fertil Steril. 2006;85(6):1684-96. Full Text: Exclude-Not relevant to any question. [pmid: 16677636].
Cramer DW, Liberman RF, Powers D, et al. Recent trends in assisted reproductive techniques and associated outcomes. Obstet Gynecol. 2000;95(1):61-6. Full Text: Exclude Q3-Not RCT. [pmid: 10636504].
Criniti A, Thyer A, Chow G, et al. Elective single blastocyst transfer reduces twin rates without compromising pregnancy rates. Fertil Steril. 2005;84(6):1613-9. Full Text: Exclude Q3-Not RCT. [pmid: 16359954].
Crosignani PG, Luciano A, Ray A, et al. Subcutaneous depot medroxyprogesterone acetate versus leuprolide acetate in the treatment of endometriosis-associated pain. Hum Reprod. 2006;21(1):248-56. Full Text: Exclude-Not relevant to any question. [pmid: 16176939].
Cross JC. Placental function in development and disease. Reproduction, Fertility, & Development. 2006;18(12):71-6. Full Text: Exclude Q4-Background article.
Cwikel J, Gidron Y, Sheiner E. Psychological interactions with infertility among women. Eur J Obstet Gynecol Reprod Biol. 2004;117(2):126-31. Full Text: Exclude Q4-Background article. [pmid: 15541845].
D'Amato G, Caroppo E, Pasquadibisceglie A, et al. A novel protocol of ovulation induction with delayed gonadotropin-releasing hormone antagonist administration combined with high-dose recombinant follicle-stimulating hormone and clomiphene citrate for poor responders and women over 35 years. Fertil Steril. 2004;81(6):1572-7. Full Text: Exclude Q3-Not RCT. [pmid: 15193479].
D'Angelo A, Amso N. Coasting (withholding gonadotrophins) for preventing ovarian hyperstimulation syndrome [Full Review]. Cochrane Database of Systematic Reviews 2002, Issue 3. Art. No.: CD002811. DOI: 10.1002/14651858.CD002811. Full Text: Exclude-Q3-Review article (Cochrane).
D'Angelo A, Amso N. Embryo freezing for preventing ovarian hyperstimulation syndrome [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 3. Art. No.: CD002806. DOI: 10.1002/14651858.CD002806.pub2. Full Text: Exclude Q3-Review article (Cochrane).
Dafopoulos K, Griesinger G, Schultze-Mosgau A, et al. Cumulative pregnancy rate after ICSI with cryopreserved testicular tissue in non-obstructive azoospermia. Reproductive Biomedicine Online. 2005;10(4):461-6. Full Text: Exclude Q3-Not RCT. [pmid: 15901452].
Damario MA, Hammitt DG, Session DR, et al. Embryo cryopreservation at the pronuclear stage and efficient embryo use optimizes the chance for a liveborn infant from a single oocyte retrieval. Fertil Steril. 2000;73(4):767-73. Full Text: Exclude Q3-Not RCT. [pmid: 10731539].
Daniel Y, Schreiber L, Geva E, et al. Morphologic and histopathologic characteristics of placentas from twin pregnancies spontaneously conceived and from reduced and nonreduced assisted reproductive technologies. J Reprod Med. 2001;46(8):735-42. Full Text: Exclude Q4-No pregnancy outcome. [pmid: 11547648].
Dar P, Sachs GS, Strassburger D, et al. Ovarian function before and after salpingectomy in artificial reproductive technology patients. Hum Reprod. 2000;15(1):142-4. Full Text: Exclude Q3-Not RCT. [pmid: 10611204].
Das S, Dodd S, Lewis-Jones DI, et al. Do lunar phases affect conception rates in assisted reproduction?. J Assist Reprod Genet. 2005;22(1):15-8. Full Text: Exclude-Not relevant to any question. [pmid: 15807217].
Daya S. Pitfalls in the design and analysis of efficacy trials in subfertility. Hum Reprod. 2003;18(5):1005-9. Full Text: Exclude Q3-Background article. [pmid: 12721177].
Daya S. Updated meta-analysis of recombinant follicle-stimulating hormone (FSH) versus urinary FSH for ovarian stimulation in assisted reproduction. Fertil Steril. 2002;77(4):711-4. Full Text: Exclude Q3-Review article. [pmid: 11937121].
Daya S, Gunby J. Luteal phase support in assisted reproduction cycles [Full Review]. Cochrane Database of Systematic Reviews 2004, Issue 3. Art. No.: CD004830. DOI: 10.1002/14651858.CD004830. Full Text: Exclude Q3-Review article (Cochrane).
Dayal MB, Dubey A, Frankfurter D, et al. Second cycle: to hatch or not to hatch?. Fertil Steril. 2007;88(3):718-20. Full Text: Exclude Q3-Not RCT. [pmid: 17320876].
De Geyter C, De Geyter M, Steimann S, et al. Comparative birth weights of singletons born after assisted reproduction and natural conception in previously infertile women. Hum Reprod. 2006;21(3):705-12. Full Text: Exclude Q4-No 2×2 table. [pmid: 16284064].
de Jong D, Eijkemans MJ, Beckers NG, et al. The added value of embryo cryopreservation to cumulative ongoing pregnancy rates per IVF treatment: is cryopreservation worth the effort?. J Assist Reprod Genet. 2002;19(12):561-8. Full Text: Exclude Q3-Not RCT. [pmid: 12503888].
de los Santos MJ, Mercader A, Galan A, et al. Implantation rates after two, three, or five days of embryo culture. Placenta. 2003;24(Suppl B):S13-9. Full Text: Exclude Q3-Not RCT. [pmid: 14559025].
De Neubourg D, Mangelschots K, Van Royen E, et al. Singleton pregnancies are as affected by ovarian hyperstimulation syndrome as twin pregnancies. Fertil Steril. 2004;82(6):1691-3. Full Text: Exclude Q2-Not RCT; Full Text: Include Q4. [pmid: 15589884].
de Oliveira NM, Vaca Sanchez R, Rodriguez Fiesta S, et al. Pregnancy with frozen-thawed and fresh testicular biopsy after motile and immotile sperm microinjection, using the mechanical touch technique to assess viability. Hum Reprod. 2004;19(2):262-5. Full Text: Exclude Q3-Not RCT. [pmid: 14747164].
De Placido G, Wilding M, Stina I, et al. The effect of ease of transfer and type of catheter used on pregnancy and implantation rates in an IVF program. J Assist Reprod Genet. 2002;19(1):14-8. Full Text: Exclude Q3-Not RCT. [pmid: 11893010].
De Sutter P, Van der Elst J, Coetsier T, et al. Single embryo transfer and multiple pregnancy rate reduction in IVF/ICSI: a 5-year appraisal. Reproductive Biomedicine Online. 2003;6(4):464-9. Full Text: Exclude Q3-Not RCT. [pmid: 12831596].
De Vos A, Van De Velde H, Joris H, et al. Influence of individual sperm morphology on fertilization, embryo morphology, and pregnancy outcome of intracytoplasmic sperm injection. Fertil Steril. 2003;79(1):42-8. Full Text: Exclude Q3-Not RCT. [pmid: 12524062].
Dean NL, Phillips SJ, Buckett WM, et al. Impact of reducing the number of embryos transferred from three to two in women under the age of 35 who produced three or more high-quality embryos. Fertil Steril. 2000;74(4):820-3. Full Text: Exclude Q3-Not RCT. [pmid: 11020531].
DeBaun MR, Niemitz EL, Feinberg AP. Association of in vitro fertilization with Beckwith-Wiedemann syndrome and epigenetic alterations of LIT1 and H19. Am J Hum Genet. 2003;72(1):156-60. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 12439823]. [pmcid: 378620].
Debrock S, Spiessens C, Meuleman C, et al. New Belgian legislation regarding the limitation of transferable embryos in in vitro fertilization cycles does not significantly influence the pregnancy rate but reduces the multiple pregnancy rate in a threefold way in the Leuven University Fertility Center. Fertil Steril. 2005;83(5):1572-4. Full Text: Exclude Q3-Not RCT. [pmid: 15866610].
Delvigne A, Kostyla K, Murillo D, et al. Oocyte quality and IVF outcome after coasting to prevent ovarian hyperstimulation syndrome. International Journal of Fertility & Womens Medicine. 2003;48(1):25-31. Full Text: Exclude Q3-Not RCT.
DeVane GW, Gangrade BK, Wilson R, et al. Optimal pregnancy outcome in a minimal-stimulation in vitro fertilization program. Am J Obstet Gynecol. 2000;183(2):309-13. discussion 313–5. Full Text: Exclude Q3-Not RCT. [pmid: 10942463].
Dickey RP, Taylor SN, Lu PY, et al. Relationship of follicle numbers and estradiol levels to multiple implantation in 3,608 intrauterine insemination cycles. Fertil Steril. 2001;75(1):69-78. Full Text: Exclude Q2-Not RCT; Full Text: Exclude Q3-Not RCT. [pmid: 11163819].
Dickey RP, Taylor SN, Lu PY, et al. Risk factors for high-order multiple pregnancy and multiple birth after controlled ovarian hyperstimulation: results of 4,062 intrauterine insemination cycles. Fertil Steril. 2005;83(3):671-83. Full Text: Exclude Q2-Not RCT. [pmid: 15749497].
Ding J, Pry M, Rana N, et al. Improved outcome of frozen-thawed blastocyst transfer with Menezo's two-step thawing compared to the stepwise thawing protocol. J Assist Reprod Genet. 2004;21(6):203-10. Full Text: Exclude Q3-Not RCT. [pmid: 15526975].
Dirnfeld L, Paz M, Yshai D, et al. The impact of early testicular sperm extraction or cryopreservation on the outcome of intracytoplasmic sperm injection—a randomized controlled study. J Assist Reprod Genet. 2003;20(6):205-9. Full Text: Exclude Q3-Not RCT. [pmid: 12877250].
Do Amaral VF, Ferriani RA, Dos Reis RM, et al. Effect of inseminated volume on intrauterine insemination. J Assist Reprod Genet. 2001;18(8):413-6. Full Text: Exclude Q2-Not RCT. [pmid: 11599460].
Doggrell SA. Metformin & lifestyle intervention prevent Type 2 diabetes: lifestyle intervention has the greater effect. Expert Opin Pharmacother. 2002;3(7):1011-3. Full Text: Exclude Q2-Not RCT. [pmid: 12084000].
Doldi N, Persico P, Di Sebastiano F, et al. Gonadotropin-releasing hormone antagonist and metformin for treatment of polycystic ovary syndrome patients undergoing in vitro fertilization-embryo transfer. Gynecol Endocrinol. 2006;22(5):235-8. Full Text: Exclude Q3-No relevant outcomes. [pmid: 16785142].
Donderwinkel PF, van der Vaart H, Wolters VM, et al. Treatment of patients with long-standing unexplained subfertility with in vitro fertilization. Fertil Steril. 2000;73(2):334-7. Full Text: Exclude Q3-Not RCT. [pmid: 10685539].
Drakakis P, Loutradis D, Kallianidis K, et al. A comparative study of the effect of ovarian stimulation protocols with different gonadotropin preparations on the biological and clinical parameters of the outcome of intracytoplasmic sperm injection. Clin Exp Obstet Gynecol. 2002;29(4):286-9. Full Text: Exclude Q3-Not RCT. [pmid: 12635747].
Dumoulin JC, Coonen E, Bras M, et al. Comparison of in-vitro development of embryos originating from either conventional in-vitro fertilization or intracytoplasmic sperm injection. Hum Reprod. 2000;15(2):402-9. Full Text: Exclude Q3-Not RCT. [pmid: 10655313].
Ebner T, Moser M, Sommergruber M, et al. Complete oocyte activation failure after ICSI can be overcome by a modified injection technique. Hum Reprod. 2004;19(8):1837-41. Full Text: Exclude Q3-Not RCT. [pmid: 15166130].
Ebner T, Moser M, Yaman C, et al. Prospective hatching of embryos developed from oocytes exhibiting difficult oolemma penetration during ICSI. Hum Reprod. 2002;17(5):1317-20. Full Text: Exclude Q3-Data not per patient. [pmid: 11980758].
Ecochard R, Mathieu C, Royere D, et al. A randomized prospective study comparing pregnancy rates after clomiphene citrate and human menopausal gonadotropin before intrauterine insemination. Fertil Steril. 2000;73(1):90-3. Full Text: Exclude Q2-Unable to calculate pregnancy rate. [pmid: 10632419].
Edwards RG. Human implantation: the last barrier in assisted reproduction technologies?. Reproductive Biomedicine Online. 2006;13(6):887-904. Full Text: Exclude Q4-Background article. [pmid: 17169215].
Ehrmann DA. Polycystic ovary syndrome. N Engl J Med. 2005;352(12):1223-36. Full Text: Exclude Q2-Background article. [pmid: 15788499].
Eijkemans MJ, Heijnen EM, de Klerk C, et al. Comparison of different treatment strategies in IVF with cumulative live birth over a given period of time as the primary end-point: methodological considerations on a randomized controlled non-inferiority trial. Hum Reprod. 2006;21(2):344-51. Full Text: Exclude Q3-Not RCT. [pmid: 16239317].
Eijkemans MJ, Imani B, Mulders AG, et al. High singleton live birth rate following classical ovulation induction in normogonadotrophic anovulatory infertility (WHO 2). Hum Reprod. 2003;18(11):2357-62. Full Text: Exclude Q2-Not RCT. [pmid: 14585887].
El-Nemr A, Bhide M, Khalifa Y, et al. Clinical evaluation of three different gonadotrophin-releasing hormone analogues in an IVF programme: a prospective study. Eur J Obstet Gynecol Reprod Biol. 2002;103(2):140-5. Full Text: Exclude Q3-Not RCT. [pmid: 12069736].
El-Sheikh MM, Hussein M, Fouad S, et al. Limited ovarian stimulation (LOS), prevents the recurrence of severe forms of ovarian hyperstimulation syndrome in polycystic ovarian disease. Eur J Obstet Gynecol Reprod Biol. 2001;94(2):245-9. Full Text: Exclude Q3-Not RCT. [pmid: 11165733].
Elimian A, Demsky M, Figueroa R, et al. The influence of IVF, multiple gestation and miscarriage on the acceptance of genetic amniocentesis. Prenat Diagn. 2003;23(6):501-3. Full Text: Exclude-Not relevant to any question. [pmid: 12813766].
Elizur SE, Levron J, Shrim A, et al. Monozygotic twinning is not associated with zona pellucida micromanipulation procedures but increases with high-order multiple pregnancies. Fertil Steril. 2004;82(2):500-1. Full Text: Exclude Q3-Not RCT. [pmid: 15302315].
Elliott JP. High-order multiple gestations. Semin Perinatol. 2005;29(5):305-11. Full Text: Exclude Q4-Background article. [pmid: 16360489].
Emery M, Beran MD, Darwiche J, et al. Results from a prospective, randomized, controlled study evaluating the acceptability and effects of routine pre-IVF counselling. Hum Reprod. 2003;18(12):2647-53. Full Text: Exclude Q3-No pregnancy outcome. [pmid: 14645186].
Engel JB, Ludwig M, Felberbaum R, et al. Use of cetrorelix in combination with clomiphene citrate and gonadotrophins: a suitable approach to ‘friendly IVF’?. Hum Reprod. 2002;17(8):2022-6. Full Text: Exclude Q3-No pregnancy outcome. [pmid: 12151431].
Engmann L, Benadiva C. GnRH agonist (buserelin) or HCG for ovulation induction in GnRH antagonist IVF/ICSI cycles: a prospective randomized study. Hum Reprod. 2005;20(11):3258-60. author reply 3260. Full Text: Exclude Q3-Not RCT. [pmid: 16246862].
Engmann L, Siano L, Schmidt D, et al. Outcome of in vitro fertilization treatment in patients who electively inseminate a limited number of oocytes to avoid creating surplus human embryos for cryopreservation. Fertil Steril. 2005;84(5):1406-10. Full Text: Exclude Q3-Not RCT. [pmid: 16275236].
Ericson A, Kallen B. Congenital malformations in infants born after IVF: a population-based study. Hum Reprod. 2001;16(3):504-9. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 11228220].
Escriba MJ, Bellver J, Bosch E, et al. Delaying the initiation of progesterone supplementation until the day of fertilization does not compromise cycle outcome in patients receiving donated oocytes: a randomized study. Fertil Steril. 2006;86(1):92-7. Full Text: Exclude Q3-Donor egg. [pmid: 16818032].
Eskandar MA. Does the addition of a gonadotropin-releasing hormone agonist improve the pregnancy rate in intrauterine insemination? A prospective controlled trial. Gynecol Endocrinol. 2007;23(10):551-5. Full Text: Exclude Q2-Not RCT. [pmid: 17891598].
Eskandar MA, Abou-Setta AM, El-Amin M, et al. Removal of cervical mucus prior to embryo transfer improves pregnancy rates in women undergoing assisted reproduction. Reproductive Biomedicine Online. 2007;14(3):308-13. Full Text: Exclude Q3-Not RCT. [pmid: 17359583].
Estes SJ, Hoover LM, Smith SE, et al. Comparison of pregnancy, implantation, and multiple gestation rates for day 3 versus day 5 embryo transfers. J Assist Reprod Genet. 2003;20(10):409-12. Full Text: Exclude Q3-Not RCT. [pmid: 14649380].
Farhi J, Weissman A, Nahum H, et al. Zygote intrafallopian transfer in patients with tubal factor infertility after repeated failure of implantation with in vitro fertilization-embryo transfer. Fertil Steril. 2000;74(2):390-3. Full Text: Exclude Q3-Not RCT. [pmid: 10927065].
Farhi J, Weissman A, Steinfeld Z, et al. Estradiol supplementation during the luteal phase may improve the pregnancy rate in patients undergoing in vitro fertilization-embryo transfer cycles. Fertil Steril. 2000;73(4):761-6. Full Text: Exclude Q3-Not RCT. [pmid: 10731538].
Farquhar C, Lilford RJ, Marjoribanks J, et al. Laparoscopic ‘drilling’ by diathermy or laser for ovulation induction in anovulatory polycystic ovary syndrome [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 3. Art. No.: CD001122. DOI: 10.1002/14651858.CD001122.pub3. Full Text: Exclude Q2-Review article (Cochrane).
Farquhar CM. The role of ovarian surgery in polycystic ovary syndrome. Best Pract Res Clin Obstet Gynaecol. 2004;18(5):789-802. Full Text: Exclude Q2-Background article. [pmid: 15380147].
Fasouliotis SJ, Laufer N, Sabbagh-Ehrlich S, et al. Gonadotropin-releasing hormone (GnRH)-antagonist versus GnRH-agonist in ovarian stimulation of poor responders undergoing IVF. J Assist Reprod Genet. 2003;20(11):455-60. Full Text: Exclude Q3-Not RCT. [pmid: 14714824].
Fedorcsak P, Dale PO, Storeng R, et al. The effect of metformin on ovarian stimulation and in vitro fertilization in insulin-resistant women with polycystic ovary syndrome: an open-label randomized cross-over trial. Gynecol Endocrinol. 2003;17(3):207-14. Full Text: Exclude Q2-No 2×2 table; Full Text: Exclude Q3-No 2×2 table. [pmid: 12857428].
Fekkes M, Buitendijk SE, Verrips GH, et al. Health-related quality of life in relation to gender and age in couples planning IVF treatment. Hum Reprod. 2003;18(7):1536-43. Full Text: Exclude-Not relevant to any question. [pmid: 12832385].
Felberbaum RE, Albano C, Ludwig M, et al. Ovarian stimulation for assisted reproduction with HMG and concomitant midcycle administration of the GnRH antagonist cetrorelix according to the multiple dose protocol: a prospective uncontrolled phase III study. Hum Reprod. 2000;15(5):1015-20. Full Text: Exclude Q3-Not RCT. [pmid: 10783344].
Ferlitsch K, Sator MO, Gruber DM, et al. Body mass index, follicle-stimulating hormone and their predictive value in in vitro fertilization. J Assist Reprod Genet. 2004;21(12):431-6. Full Text: Exclude Q3-Not RCT. [pmid: 15704518].
Fernandez H, Gervaise A. Ectopic pregnancies after infertility treatment: modern diagnosis and therapeutic strategy. Hum Reprod Update. 2004;10(6):503-13. Full Text: Exclude Q4-Background article. [pmid: 15388673].
Ferrara I, Balet R, Grudzinskas JG. Intrauterine donor insemination in single women and lesbian couples: a comparative study of pregnancy rates. Hum Reprod. 2000;15(3):621-5. Full Text: Exclude-Not relevant to any question. [pmid: 10686208].
Ferraretti AP, Gianaroli L, Magli MC, et al. Exogenous luteinizing hormone in controlled ovarian hyperstimulation for assisted reproduction techniques. Fertil Steril. 2004;82(6):1521-6. Full Text: Exclude Q3-Not RCT. [pmid: 15589853].
Fiddelers AA, van Montfoort AP, Dirksen CD, et al. Single versus double embryo transfer: cost-effectiveness analysis alongside a randomized clinical trial. Hum Reprod. 2006;21(8):2090-7. Full Text: Exclude Q3-Cost analysis of Van Montfoort #56560. [pmid: 16613886].
Fleming R, Rehka P, Deshpande N, et al. Suppression of LH during ovarian stimulation: effects differ in cycles stimulated with purified urinary FSH and recombinant FSH. Hum Reprod. 2000;15(7):1440-5. Full Text: Exclude Q2-Not RCT. [pmid: 10875848].
Franco JG Jr, Baruffi RL, Mauri AL, et al. Prospective randomized comparison of ovarian blockade with nafarelin versus leuprolide during ovarian stimulation with recombinant FSH in an ICSI program. J Assist Reprod Genet. 2001;18(11):593-7. Full Text: Exclude Q3-Data not per patient. [pmid: 11804427].
Franco JG Jr, Martins AM, Baruffi RL, et al. Best site for embryo transfer: the upper or lower half of endometrial cavity?. Hum Reprod. 2004;19(8):1785-90. Full Text: Exclude Q3-Data not per patient. [pmid: 15218006].
Frankfurter D, Trimarchi JB, Silva CP, et al. Middle to lower uterine segment embryo transfer improves implantation and pregnancy rates compared with fundal embryo transfer. Fertil Steril. 2004;81(5):1273-7. Full Text: Exclude Q3-Not RCT. [pmid: 15136089].
Frattarelli JL, Leondires MP, Miller BT, et al. Intracytoplasmic sperm injection increases embryo fragmentation without affecting clinical outcome. J Assist Reprod Genet. 2000;17(4):207-12. Full Text: Exclude Q3-Not RCT. [pmid: 10955244].
Frederick J, DaCosta V, Wynter S, et al. Effect of the oral contraceptive pill on patients undergoing controlled ovarian hyperstimulation. West Indian Med J. 2004;53(1):39-43. Full Text: Exclude Q2-Not RCT. [pmid: 15114893].
Friedler S, Raziel A, Schachter M, et al. Outcome of first and repeated testicular sperm extraction and ICSI in patients with non-obstructive azoospermia. Hum Reprod. 2002;17(9):2356-61. Full Text: Exclude Q3-Not RCT. [pmid: 12202425].
Friling R, Axer-Siegel R, Hersocovici Z, et al. Retinopathy of prematurity in assisted versus natural conception and singleton versus multiple births. Ophthalmology. 2007;114(2):321-4. Full Text: Exclude Q4-Not true case-control or cohort. [pmid: 17270680].
Frydman N, Fanchin R, Le Du A, et al. Improvement of IVF results and optimisation of quality control by using intermittent activity. Reproductive Biomedicine Online. 2004;9(5):521-8. Full Text: Exclude Q3-Not RCT. [pmid: 15588470].
Fujii S, Sato S, Fukui A, et al. Continuous administration of gonadotrophin-releasing hormone agonist during the luteal phase in IVF. Hum Reprod. 2001;16(8):1671-5. Full Text: Exclude Q3-Not RCT. [pmid: 11473961].
Funnell CL, Dabbs TR. Assisted conception and retinopathy of prematurity: 8-year follow-up study. Eye. 2007;21(3):383-6. Full Text: Exclude Q4-Not true case-control or cohort. [pmid: 16410811].
Garcia-Velasco JA, Isaza V, Martinez-Salazar J, et al. Transabdominal ultrasound-guided embryo transfer does not increase pregnancy rates in oocyte recipients. Fertil Steril. 2002;78(3):534-9. Full Text: Exclude Q3-Donor egg. [pmid: 12215329].
Garcia-Velasco JA, Zuniga A, Pacheco A, et al. Coasting acts through downregulation of VEGF gene expression and protein secretion. Hum Reprod. 2004;19(7):1530-8. Full Text: Exclude Q3-Not RCT. [pmid: 15155606].
Garrido N, Meseguer M, Bellver J, et al. Report of the results of a 2 year programme of sperm wash and ICSI treatment for human immunodeficiency virus and hepatitis C virus serodiscordant couples. Hum Reprod. 2004;19(11):2581-6. Full Text: Exclude Q3-Not RCT. [pmid: 15319386].
Gauthier E, Paoletti X, Clavel-Chapelon F, et al. Breast cancer risk associated with being treated for infertility: results from the French E3N cohort study. Hum Reprod. 2004;19(10):2216-21. Full Text: Exclude Q2-Not RCT; Full Text: Include Q4. [pmid: 15271872].
Ge HS, Huang XF, Zhang W, et al. Exposure to human chorionic gonadotropin during in vitro maturation does not improve the maturation rate and developmental potential of immature oocytes from patients with polycystic ovary syndrome. Fertil Steril. 2008;89(1):98-103. Full Text: Exclude Q3-Data not per patient. [pmid: 17524398].
Geipel A, Berg C, Katalinic A, et al. Different preferences for prenatal diagnosis in pregnancies following assisted reproduction versus spontaneous conception. Reproductive Biomedicine Online. 2004;8(1):119-24. Full Text: Exclude-Not relevant to any question. [pmid: 14759300].
Gergely RZ, DeUgarte CM, Danzer H, et al. Three dimensional/four dimensional ultrasound-guided embryo transfer using the maximal implantation potential point. Fertil Steril. 2005;84(2):500-3. Full Text: Exclude Q3-Not RCT. [pmid: 16084896].
Germond M, Primi MP, Urner F, et al. Number of transferred embryos: how to reduce multiple pregnancies. Ann N Y Acad Sci. 2004;1034:93-100. Full Text: Exclude Q3-Not RCT. [pmid: 15731302].
Germond M, Urner F, Chanson A, et al. What is the most relevant standard of success in assisted reproduction?: The cumulated singleton/twin delivery rates per oocyte pick-up: the CUSIDERA and CUTWIDERA. Hum Reprod. 2004;19(11):2442-4. Full Text: Exclude Q3-Not RCT. [pmid: 15358719].
Gerris J, De Neubourg D, Mangelschots K, et al. Elective single day 3 embryo transfer halves the twinning rate without decrease in the ongoing pregnancy rate of an IVF/ICSI programme. Hum Reprod. 2002;17(10):2626-31. Full Text: Exclude Q3-Not RCT. [pmid: 12351539].
Gerris J, De Sutter P, De Neubourg D, et al. A real-life prospective health economic study of elective single embryo transfer versus two-embryo transfer in first IVF/ICSI cycles. Hum Reprod. 2004;19(4):917-23. Full Text: Exclude Q3-Not RCT. [pmid: 14990547].
Geva E, Yovel I, Lerner-Geva L, et al. Intrauterine insemination before transfer of frozen-thawed embryos may improve the pregnancy rate for couples with unexplained infertility: preliminary results of a randomized prospective study. Fertil Steril. 2000;73(4):755-60. Full Text: Exclude Q3-Data not per patient. [pmid: 10731537].
Ghobara T, Vandekerckhove P. Cycle regimens for frozen-thawed embryo transfer [Full Review]. Cochrane Database of Systematic Reviews 2008, Issue 1. Art. No.: CD003414. DOI: 10.1002/14651858.CD003414.pub2. Full Text: Exclude Q3-Review article (Cochrane).
Giannini P, Piscitelli C, Giallonardo A, et al. Number of embryos transferred and implantation. Ann N Y Acad Sci. 2004;1034:278-83. Full Text: Exclude Q3-Not RCT. [pmid: 15731319].
Gil-Salom M, Romero J, Rubio C, et al. Intracytoplasmic sperm injection with cryopreserved testicular spermatozoa. Mol Cell Endocrinol. 2000;169(12):15-9. Full Text: Exclude Q3-Not RCT. [pmid: 11155947].
Gilboa Y, Bar-Hava I, Fisch B, et al. Does intravaginal probiotic supplementation increase the pregnancy rate in IVF-embryo transfer cycles?. Reproductive Biomedicine Online. 2005;11(1):71-5. Full Text: Exclude Q3-Not RCT. [pmid: 16102292].
Gissler M, Klemetti R, Sevon T, et al. Monitoring of IVF birth outcomes in Finland: a data quality study. BMC Medical Informatics & Decision Making. 2004;4(1):3. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 15070411]. [pmcid: 385243].
Gissler M, Tiitinen A. IVF treatments and their outcomes in Finland in the 1990s. Acta Obstet Gynecol Scand. 2001;80(10):937-44. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 11580739].
Giulini S, Pesce F, Madgar I, et al. Influence of multiple transrectal electroejaculations on semen parameters and intracytoplasmic sperm injection outcome. Fertil Steril. 2004;82(1):200-4. Full Text: Exclude Q3-Not RCT. [pmid: 15237012].
Gleicher N, Brown T, Dudkiewicz A, et al. Estradiol/progesterone substitution in the luteal phase improves pregnancy rates in stimulated cycles—but only in younger women. Early Pregnancy [Electronic Resource]. 2000;4(1):64-73. Full Text: Exclude Q3-Not IVF.
Gleicher N, Karande V. Generic human menopausal gonadotropin (hMG) in place of more costly follicle-stimulating hormone (FSH) for routine ovulation induction. J Assist Reprod Genet. 2000;17(9):489-95. Full Text: Exclude Q3-Not RCT. [pmid: 11155320].
Gleicher N, Oleske DM, Tur-Kaspa I, et al. Reducing the risk of high-order multiple pregnancy after ovarian stimulation with gonadotropins. N Engl J Med. 2000;343(1):2-7. Full Text: Exclude Q2-Not RCT. [pmid: 10882762].
Glueck CJ, Bornovali S, Pranikoff J, et al. Metformin, pre-eclampsia, and pregnancy outcomes in women with polycystic ovary syndrome. Diabet Med. 2004;21(8):829-36. Full Text: Exclude Q4-Outcomes not correlated with history or infertility or treatment. [pmid: 15270785].
Glueck CJ, Goldenberg N, Pranikoff J, et al. Height, weight, and motor-social development during the first 18 months of life in 126 infants born to 109 mothers with polycystic ovary syndrome who conceived on and continued metformin through pregnancy. Hum Reprod. 2004;19(6):1323-30. Full Text: Exclude Q4-PCOS, not infertility. [pmid: 15117896].
Glueck CJ, Phillips H, Cameron D, et al. Continuing metformin throughout pregnancy in women with polycystic ovary syndrome appears to safely reduce first-trimester spontaneous abortion: a pilot study. Fertil Steril. 2001;75(1):46-52. Full Text: Exclude Q2-Not RCT. [pmid: 11163815].
Glueck CJ, Wang P, Goldenberg N, et al. Pregnancy loss, polycystic ovary syndrome, thrombophilia, hypofibrinolysis, enoxaparin, metformin. Clinical & Applied Thrombosis/Hemostasis. 2004;10(4):323-34. Full Text: Exclude Q2-Not RCT. [pmid: 15497018].
Glueck CJ, Wang P, Goldenberg N, et al. Pregnancy outcomes among women with polycystic ovary syndrome treated with metformin. Hum Reprod. 2002;17(11):2858-64. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 12407039].
Glueck CJ, Wang P, Kobayashi S, et al. Metformin therapy throughout pregnancy reduces the development of gestational diabetes in women with polycystic ovary syndrome. Fertil Steril. 2002;77(3):520-5. Full Text: Exclude Q4-Outcomes not correlated with history or infertility or treatment. [pmid: 11872206].
Gojnic M, Jeremic K, Boskovic V, et al. Perinatal outcome in multiple pregnancies—spontaneous gestation versus. Clin Exp Obstet Gynecol. 2005;32(1):65-7. Full Text: Exclude Q4-Data inconsistent. [pmid: 15864943].
Goker EN, Sendag F, Levi R, et al. Comparison of the ICSI outcome of ejaculated sperm with normal, abnormal parameters and testicular sperm. Eur J Obstet Gynecol Reprod Biol. 2002;104(2):129-36. Full Text: Exclude Q3-Not RCT. [pmid: 12206925].
Goldfarb JM, Desai N. Follitropin-alpha versus human menopausal gonadotropin in an in vitro fertilization program. Fertil Steril. 2003;80(5):1094-9. Full Text: Exclude Q3-Not RCT. [pmid: 14607554].
Gordts S, Campo R, Puttemans P, et al. Belgian legislation and the effect of elective single embryo transfer on IVF outcome. Reproductive Biomedicine Online. 2005;10(4):436-41. Full Text: Exclude Q3-Not RCT. [pmid: 15901449].
Gorkemli H, Camus M, Clasen K. Adnexal torsion after gonadotrophin ovulation induction for IVF or ICSI and its conservative treatment. Arch Gynecol Obstet. 2002;267(1):4-6. Full Text: Exclude Q2-Not RCT. [pmid: 12410364].
Gorrill MJ, Sadler-Fredd K, Patton PE, et al. Multiple gestations in assisted reproductive technology: can they be avoided with blastocyst transfers?. Am J Obstet Gynecol. 2001;184(7):1471-5. discussion 1475–7. Full Text: Exclude Q3-Not RCT. [pmid: 11408870].
Goto S, Kadowaki T, Hashimoto H, et al. Stimulation of endometrium embryo transfer (SEET): injection of embryo culture supernatant into the uterine cavity before blastocyst transfer can improve implantation and pregnancy rates. Fertil Steril. 2007;88(5):1339-43. Full Text: Exclude Q3-Not RCT. [pmid: 17559843].
Goto S, Shiotani M, Kitagawa M, et al. Effectiveness of two-step (consecutive) embryo transfer in patients who have two embryos on day 2: comparison with cleavage-stage embryo transfer. Fertil Steril. 2005;83(3):721-3. Full Text: Exclude Q3-Not RCT. [pmid: 15749504].
Goto S, Takebayashi K, Shiotani M, et al. Effectiveness of 2-step (consecutive) embryo transfer. Comparison with cleavage-stage transfer. J Reprod Med. 2003;48(5):370-4. Full Text: Exclude Q3-Not RCT. [pmid: 12815912].
Goverde AJ, Lambalk CB, McDonnell J, et al. Further considerations on natural or mild hyperstimulation cycles for intrauterine insemination treatment: effects on pregnancy and multiple pregnancy rates. Hum Reprod. 2005;20(11):3141-6. Full Text: Exclude Q2-Not RCT (secondary analysis of 1 arm of previous RCT). [pmid: 16037113].
Graziano V, Check JH, Dietterich C, et al. A comparison of luteal phase support in graduated estradiol/progesterone replacement cycles using intramuscular progesterone alone versus combination with vaginal suppositories on outcome following frozen embryo transfer. Clin Exp Obstet Gynecol. 2005;32(2):93-4. Full Text: Exclude Q2-Not RCT. [pmid: 16108388].
Griebel CP, Halvorsen J, Golemon TB, et al. Management of spontaneous abortion. Am Fam Physician. 2005;72(7):1243-50. Full Text: Exclude Q4-Background article. [pmid: 16225027].
Griesinger G, Felberbaum R, Diedrich K. GnRH antagonists in ovarian stimulation: a treatment regimen of clinicians' second choice? Data from the German national IVF registry. Hum Reprod. 2005;20(9):2373-5. Full Text: Exclude Q2-Not RCT. [pmid: 15932915].
Griffiths M, Kennedy CR, Rai J, et al. Should cryopreserved epididymal or testicular sperm be recovered from obstructive azoospermic men for ICSI?. BJOG. 2004;111(11):1289-93. Full Text: Exclude Q3-Not RCT. [pmid: 15521877].
Grochowski D, Wolczynski S, Kuczynski W, et al. Correctly timed coasting reduces the risk of ovarian hyperstimulation syndrome and gives good cycle outcome in an in vitro fertilization program. Gynecol Endocrinol. 2001;15(3):234-8. Full Text: Exclude Q3-Not RCT. [pmid: 11447736].
Guerif F, Bidault R, Gasnier O, et al. Efficacy of blastocyst transfer after implantation failure. Reproductive Biomedicine Online. 2004;9(6):630-6. Full Text: Exclude Q3-Not RCT. [pmid: 15670410].
Guerif F, Cadoret V, Poindron J, et al. Overnight incubation improves selection of frozen-thawed blastocysts for transfer: preliminary study using supernumerary embryos. Theriogenology. 2003;60(8):1457-66. Full Text: Exclude Q3-Not RCT. [pmid: 14519467].
Guerif F, Fourquet F, Marret H, et al. Cohort follow-up of couples with primary infertility in an ART programme using frozen donor semen. Hum Reprod. 2002;17(6):1525-31. Full Text: Exclude Q3-Not RCT. [pmid: 12042272].
Gunby J, Daya S. IVF Directors Group of the Canadian Fertility and Andrology Society. Assisted reproductive technologies (ART) in Canada: 2002 results from the Canadian ART Register. Fertil Steril. 2006;86(5):1356-64. Full Text: Exclude-Not relevant to any question. [pmid: 17070192].
Habana AE, Palter SF. Is tubal embryo transfer of any value? A meta-analysis and comparison with the Society for Assisted Reproductive Technology database. Fertil Steril. 2001;76(2):286-93. Full Text: Exclude Q3-Review article. [pmid: 11476774].
Hammitt DG, Sattler CA, Manes ML, et al. Selection of embryos for day-3 transfer at the pronuclear-stage and pronuclear-stage cryopreservation results in high delivery rates in fresh and frozen cycles. J Assist Reprod Genet. 2004;21(7):271-8. Full Text: Exclude Q3-Not RCT. [pmid: 15526985].
Hansen M, Sullivan E, Jequier AM, et al. Practitioner reporting of birth defects in children born following assisted reproductive technology: Does it still have a role in surveillance of birth defects?. Hum Reprod. 2007;22(2):516-20. Full Text: Exclude-Not relevant to any question. [pmid: 17021189].
Hardiman P, Pillay OC, Atiomo W. Polycystic ovary syndrome and endometrial carcinoma [erratum appears in Lancet. 2003 Sep 27;362(9389):1082]. Lancet. 2003;361(9371):1810-2. Full Text: Exclude Q4-Background article. [pmid: 12781553].
Harlin J, Aanesen A, Csemiczky G, et al. Delivery rates following IVF treatment, using two recombinant FSH preparations for ovarian stimulation. Hum Reprod. 2002;17(2):304-9. Full Text: Exclude Q3-Not RCT. [pmid: 11821268].
Harlin J, Csemiczky G, Wramsby H, et al. Recombinant follicle stimulating hormone in in-vitro fertilization treatment-clinical experience with follitropin alpha and follitropin beta. Hum Reprod. 2000;15(2):239-44. Full Text: Exclude Q3-Data not per patient. [pmid: 10655291].
Harper K, Proctor M, Hughes E. Growth hormone for in vitro fertilization [Full Review]. Cochrane Database of Systematic Reviews 2003, Issue 3. Art. No.: CD000099. DOI: 10.1002/14651858.CD000099. Full Text: Exclude Q3-Review article (Cochrane).
Hashimoto S, Fukuda A, Murata Y, et al. Effect of aspiration vacuum on the developmental competence of immature human oocytes retrieved using a 20-gauge needle. Reproductive Biomedicine Online. 2007;14(4):444-9. Full Text: Exclude Q3-Not RCT. [pmid: 17425825].
Hauser R, Yogev L, Amit A, et al. Severe hypospermatogenesis in cases of nonobstructive azoospermia: should we use fresh or frozen testicular spermatozoa?. J Androl. 2005;26(6):772-8. Full Text: Exclude Q3-Not RCT. [pmid: 16291973].
Healey S, Tan SL, Tulandi T, et al. Effects of letrozole on superovulation with gonadotropins in women undergoing intrauterine insemination. Fertil Steril. 2003;80(6):1325-9. Full Text: Exclude Q2-Not RCT. [pmid: 14667860].
Hearns-Stokes RM, Miller BT, Scott L, et al. Pregnancy rates after embryo transfer depend on the provider at embryo transfer. Fertil Steril. 2000;74(1):80-6. Full Text: Exclude Q3-Not RCT. [pmid: 10899501].
Hellberg D, Blennborn M, Nilsson S. Defining women who are prone to have twins in in vitro fertilization—a necessary step towards single embryo transfer. J Assist Reprod Genet. 2005;22(5):199-206. Full Text: Exclude Q3-Not RCT. [pmid: 16047581].
Hellmuth E, Damm P, Molsted-Pedersen L. Oral hypoglycaemic agents in 118 diabetic pregnancies. Diabet Med. 2000;17(7):507-11. Full Text: Exclude Q4-Outcomes not correlated with history or infertility or treatment. [pmid: 10972579].
Helmerhorst FM, Perquin DA, Donker D, et al. Perinatal outcome of singletons and twins after assisted conception: a systematic review of controlled studies. BMJ. 2004;328(7434):261-6. Full Text: Exclude Q4-Review article. [pmid: 14742347]. [pmcid: 324454].
Henne MB, Zhang M, Paroski S, et al. Comparison of obstetric outcomes in recipients of donor oocytes vs. women of advanced maternal age with autologous oocytes. J Reprod Med. 2007;52(7):585-90. Full Text: Exclude Q4-Donor egg. [pmid: 17847755].
Hennelly B, Harrison RF, Kelly J, et al. Spontaneous conception after a successful attempt at in vitro fertilization/intracytoplasmic sperm injection. Fertil Steril. 2000;73(4):774-8. Full Text: Exclude Q4-No outcomes of interest. [pmid: 10731540].
Ho JY, Chen MJ, Yi YC, et al. The effect of preincubation period of oocytes on nuclear maturity, fertilization rate, embryo quality, and pregnancy outcome in IVF and ICSI. J Assist Reprod Genet. 2003;20(9):358-64. Full Text: Exclude Q3-Not RCT. [pmid: 14531646].
Hojgaard A, Ottosen LD, Kesmodel U, et al. Patient attitudes towards twin pregnancies and single embryo transfer - a questionnaire study. Hum Reprod. 2007;22(10):2673-8. Full Text: Exclude Q4-Background article. [pmid: 17766921].
Holmes A, Jauniaux E. Prospective study of parental choice for aneuploidy screening in assisted conception versus spontaneously conceived twins. Reproductive Biomedicine Online. 2004;8(2):243-5. Full Text: Exclude-Not relevant to any question. [pmid: 14989809].
Horwath D, Check JH, Choe JK, et al. Frozen embryo transfer outcome according to reason for freezing the embryos. Clin Exp Obstet Gynecol. 2005;32(1):19-20. Full Text: Exclude Q3-Not RCT. [pmid: 15864929].
Hsieh Y, Tsai H, Chang C, et al. Comparison of a single half-dose, long-acting form of gonadotropin-releasing hormone analog (GnRH-a) and a short-acting form of GnRH-a for pituitary suppression in a controlled ovarian hyperstimulation program. Fertil Steril. 2000;73(4):817-20. Full Text: Exclude Q3-Not RCT. [pmid: 10731546].
Hsieh YY, Huang CC, Cheng TC, et al. Laser-assisted hatching of embryos is better than the chemical method for enhancing the pregnancy rate in women with advanced age. Fertil Steril. 2002;78(1):179-82. Full Text: Exclude Q3-Not RCT. [pmid: 12095510].
Huang FJ, Chang SY, Lu YJ, et al. Two different timings of intrauterine insemination for non-male infertility. J Assist Reprod Genet. 2000;17(4):213-7. Full Text: Exclude Q3-Not RCT. [pmid: 10955245].
Huang FJ, Chang SY, Tsai MY, et al. Clinical implications of intracytoplasmic sperm injection using cryopreserved testicular spermatozoa from men with azoospermia. J Reprod Med. 2000;45(4):310-6. Full Text: Exclude Q3-Not RCT. [pmid: 10804487].
Hughes E, Brown J, Collins J, et al. Clomiphene citrate for unexplained subfertility in women [Full Review]. Cochrane Database of Systematic Reviews 2000, Issue 1. Art. No.: CD000057. DOI: 10.1002/14651858.CD000057. Full Text: Exclude Q2-Review article (Cochrane).
Hui PW, Lam YH, Tang MH, et al. Maternal serum pregnancy-associated plasma protein-A and free beta-human chorionic gonadotrophin in pregnancies conceived with fresh and frozen-thawed embryos from in vitro fertilization and intracytoplasmic sperm injection. Prenat Diagn. 2005;25(5):390-3. Full Text: Exclude Q3-Not RCT; Full Text: Include Q4. [pmid: 15906430].
Hull MG. Epidemiology of infertility and polycystic ovarian disease: endocrinological and demographic studies. Gynecol Endocrinol. 1987;1(3):235-45. Full Text: Exclude Q2-Background article. [pmid: 3140583].
Hunter SC, Isingo R, Boerma JT, et al. The association between HIV and fertility in a cohort study in rural Tanzania. J Biosoc Sci. 2003;35(2):189-99. Full Text: Exclude-Not relevant to any question. [pmid: 12664957].
Hurst BS, Tucker KE, Awoniyi CA, et al. Hydrosalpinx treated with extended doxycycline does not compromise the success of in vitro fertilization. Fertil Steril. 2001;75(5):1017-9. Full Text: Exclude Q3-Not RCT. [pmid: 11334919].
Hurst BS, Tucker KE, Schlaff WD. A minimally monitored assisted reproduction stimulation protocol reduces cost without compromising success. Fertil Steril. 2002;77(1):98-100. Full Text: Exclude Q3-Not RCT. [pmid: 11779597].
Hwang JL, Seow KM, Lin YH, et al. IVF versus ICSI in sibling oocytes from patients with polycystic ovarian syndrome: a randomized controlled trial. Hum Reprod. 2005;20(5):1261-5. Full Text: Exclude Q3-Data not per patient. [pmid: 15705619].
Hwu YM, Lin SY, Huang WY, et al. Ultra-short metformin pretreatment for clomiphene citrate-resistant polycystic ovary syndrome. Int J Gynaecol Obstet. 2005;90(1):39-43. Full Text: Exclude Q2-Not RCT. [pmid: 15921686].
Hyden-Granskog C, Tiitinen A. Single embryo transfer in clinical practice. Human Fertility. 2004;7(3):175-82. Full Text: Exclude Q3-Not RCT. [pmid: 15590571].
Ibanez L, Potau N, Ferrer A, et al. Reduced ovulation rate in adolescent girls born small for gestational age. J Clin Endocrinol Metab. 2002;87(7):3391-3. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 12107255].
Adamson GD, de Mouzon J. International Committee for Monitoring Assisted Reproductive Technology, et al. World collaborative report on in vitro fertilization, 2000. Fertil Steril. 2006;85(6):1586-622. Full Text: Exclude-Not relevant to any question. [pmid: 16759920].
Isaza V, Garcia-Velasco JA, Aragones M, et al. Oocyte and embryo quality after coasting: the experience from oocyte donation. Hum Reprod. 2002;17(7):1777-82. Full Text: Exclude Q3-Not RCT. [pmid: 12093839].
Isik AZ, Vicdan K. Combined approach as an effective method in the prevention of severe ovarian hyperstimulation syndrome. Eur J Obstet Gynecol Reprod Biol. 2001;97(2):208-12. Full Text: Exclude Q2-Not RCT. [pmid: 11451550].
Isiklar A, Mercan R, Balaban B, et al. Early cleavage of human embryos to the two-cell stage. A simple, effective indicator of implantation and pregnancy in intracytoplasmic sperm injection. J Reprod Med. 2002;47(7):540-4. Full Text: Exclude Q3-Not RCT. [pmid: 12170529].
Isiklar A, Mercan R, Balaban B, et al. Impact of oocyte pre-incubation time on fertilization, embryo quality and pregnancy rate after intracytoplasmic sperm injection. Reproductive Biomedicine Online. 2004;8(6):682-6. Full Text: Exclude Q3-Not RCT. [pmid: 15169586].
Ito A, Honma Y, Inamori E, et al. Developmental outcome of very low birth weight twins conceived by assisted reproduction techniques. J Perinatol. 2006;26(2):130-3. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 16319935].
Jackson RA, Gibson KA, Wu YW, et al. Perinatal outcomes in singletons following in vitro fertilization: a meta-analysis. Obstet Gynecol. 2004;103(3):551-63. Full Text: Exclude Q4-Review article. [pmid: 14990421].
Jacobs M, Stolwijk AM, Wetzels AM. The effect of insemination/injection time on the results of IVF and ICSI. Hum Reprod. 2001;16(8):1708-13. Full Text: Exclude Q3-Not RCT. [pmid: 11473969].
Jain JK, Boostanfar R, Slater CC, et al. Monozygotic twins and triplets in association with blastocyst transfer. J Assist Reprod Genet. 2004;21(4):103-7. Full Text: Exclude Q4-Data not per patient. [pmid: 15270208].
Jain JK, Kuo J. Pregnancy outcomes with increased clomiphene citrate dose. Gynecol Endocrinol. 2004;19(3):141-5. Full Text: Exclude Q2-Not RCT. [pmid: 15697075].
Jain T, Harlow BL, Hornstein MD. Insurance coverage and outcomes of in vitro fertilization. N Engl J Med. 2002;347(9):661-6. Full Text: Exclude Q3-Not RCT. [pmid: 12200554].
Jakubowicz DJ, Iuorno MJ, Jakubowicz S, et al. Effects of metformin on early pregnancy loss in the polycystic ovary syndrome. J Clin Endocrinol Metab. 2002;87(2):524-9. Full Text: Exclude Q2-Not RCT. [pmid: 11836280].
Janssens RM, Lambalk CB, Vermeiden JP, et al. In-vitro fertilization in a spontaneous cycle: easy, cheap and realistic. Hum Reprod. 2000;15(2):314-8. Full Text: Exclude Q3-Not RCT. [pmid: 10655301].
Janzen N, Goldstein M, Schlegel PN, et al. Use of electively cryopreserved microsurgically aspirated epididymal sperm with IVF and intracytoplasmic sperm injection for obstructive azoospermia. [erratum appears in Fertil Steril 2001 Jan;75(1):230]. Fertil Steril. 2000;74(4):696-701. Full Text: Exclude Q3-Not RCT. [pmid: 11020509].
Jee BC, Ku SY, Suh CS, et al. Cumulative ongoing pregnancy rate in intracytoplasmic sperm injection cycles. J Obstet Gynaecol Res. 2004;30(5):372-6. Full Text: Exclude Q3-Not RCT. [pmid: 15327451].
Jensen JR, Walker JH, Milki AA, et al. The effect of a two-hour, room temperature incubation of human spermatozoa in TEST-yolk buffer on the rate of fertilization in vitro. J Assist Reprod Genet. 2004;21(5):169-73. Full Text: Exclude Q3-No pregnancy outcome. [pmid: 15279324].
Johnson NP, Mak W, Sowter MC. Surgical treatment for tubal disease in women due to undergo in vitro fertilisation [Full Review]. Cochrane Database of Systematic Reviews 2004, Issue 3. Art. No.: CD002125. DOI: 10.1002/14651858.CD002125.pub2. Full Text: Exclude Q3-Review article (Cochrane).
Jung H, Roh HK. The effects of E2 supplementation from the early proliferative phase to the late secretory phase of the endometrium in hMG-stimulated IVF-ET. J Assist Reprod Genet. 2000;17(1):28-33. Full Text: Exclude Q3-Data not per patient. [pmid: 10754780].
Jurema MW, Vieira AD, Bankowski B, et al. Effect of ejaculatory abstinence period on the pregnancy rate after intrauterine insemination. Fertil Steril. 2005;84(3):678-81. Full Text: Exclude Q2-Not RCT. [pmid: 16169402].
Kailasam C, Keay SD, Wilson P, et al. Defining poor ovarian response during IVF cycles, in women aged <40 years, and its relationship with treatment outcome. Hum Reprod. 2004;19(7):1544-7. Full Text: Exclude Q3-Not RCT. [pmid: 15142994].
Kallen B, Finnstrom O, Nygren KG, et al. In vitro fertilization (IVF) in Sweden: infant outcome after different IVF fertilization methods. Fertil Steril. 2005;84(3):611-7. Full Text: Exclude Q3-Not RCT; Full Text: Exclude Q4 -No 2×2 table. [pmid: 16169393].
Kallen B, Finnstrom O, Nygren KG, et al. Temporal trends in multiple births after in vitro fertilisation in Sweden, 1982-2001: a register study. BMJ. 2005;331(7513):382-3. Full Text: Exclude Q3-Not RCT. [pmid: 15894553]. [pmcid: 1184249].
Kallen B, Finnstrom O, Nygren KG, et al. In vitro fertilisation in Sweden: obstetric characteristics, maternal morbidity and mortality. BJOG. 2005;112(11):1529-35. Full Text: Exclude Q4-No 2×2 table. [pmid: 16225574].
Kallen B, Olausson PO, Nygren KG. Neonatal outcome in pregnancies from ovarian stimulation. Obstet Gynecol. 2002;100(3):414-9. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 12220758].
Kansal-Kalra S, Milad MP, Grobman WA. In vitro fertilization (IVF) versus gonadotropins followed by IVF as treatment for primary infertility: a cost-based decision analysis. Fertil Steril. 2005;84(3):600-4. Full Text: Exclude Q2-Not RCT; Full Text: Exclude Q3-Not RCT. [pmid: 16169391].
Kaplan PF, Patel M, Austin DJ, et al. Assessing the risk of multiple gestation in gonadotropin intrauterine insemination cycles. Am J Obstet Gynecol. 2002;186(6):1244-7. discussion 1247–9. Full Text: Exclude Q2-Not RCT. [pmid: 12066105].
Kaponis A, Yiannakis D, Tsoukanelis K, et al. The role of ultrasonographically guided puncture of the human rete testis in the therapeutic management of nonobstructive azoospermia. Andrologia. 2003;35(2):85-92. Full Text: Exclude Q3-Not RCT. [pmid: 12653781].
Karacan M, Erkan H, Karabulut O, et al. Clinical pregnancy rates in an IVF program. Use of the flare-up protocol after failure with long regimens of GnRH-a. J Reprod Med. 2001;46(5):485-9. Full Text: Exclude Q3-Not RCT. [pmid: 11396377].
Karande V, Hazlett D, Vietzke M, et al. A prospective randomized comparison of the Wallace catheter and the Cook Echo-Tip catheter for ultrasound-guided embryo transfer. Fertil Steril. 2002;77(4):826-30. Full Text: Exclude Q3-Not RCT. [pmid: 11937141].
Kashyap S, Claman P. Polycystic ovary disease and the risk of pregnancy-induced hypertension. J Reprod Med. 2000;45(12):991-4. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 11153260].
Kashyap S, Moher D, Fung MF, et al. Assisted reproductive technology and the incidence of ovarian cancer: a meta-analysis. Obstet Gynecol. 2004;103(4):785-94. Full Text: Exclude Q2-Not RCT; Full Text: Exclude Q4-Review article. [pmid: 15051576].
Kashyap S, Wells GA, Rosenwaks Z. Insulin-sensitizing agents as primary therapy for patients with polycystic ovarian syndrome. Hum Reprod. 2004;19(11):2474-83. Full Text: Exclude Q2-Review article. [pmid: 15358717].
Kaya H, Karci M, Ozkaya O, et al. Relationship between the timing of hysterosalpingography before gamete intrafallopian transfer and the subsequent fertility outcome. J Obstet Gynaecol Res. 2004;30(6):448-53. Full Text: Exclude Q3-Not RCT. [pmid: 15566461].
Keegan DA, Krey LC, Chang HC, et al. Increased risk of pregnancy-induced hypertension in young recipients of donated oocytes. Fertil Steril. 2007;87(4):776-81. Full Text: Exclude Q4-No controls. [pmid: 17258714].
Keltz MD, Skorupski JC, Bradley K, et al. Predictors of embryo fragmentation and outcome after fragment removal in in vitro fertilization. Fertil Steril. 2006;86(2):321-4. Full Text: Exclude Q3-Not RCT. [pmid: 16824522].
Khalaf Y, El-Toukhy T, Taylor A, et al. Increasing the gonadotrophin dose in the course of an in vitro fertilization cycle does not rectify an initial poor response. Eur J Obstet Gynecol Reprod Biol. 2002;103(2):146-9. Full Text: Exclude Q3-Not RCT. [pmid: 12069737].
Khorram O, Shapiro SS, Jones JM. Transfer of nonassisted hatched and hatching human blastocysts after in vitro fertilization. Fertil Steril. 2000;74(1):163-5. Full Text: Exclude Q3-Not RCT. [pmid: 10899515].
Kim WO, Kil HK, Koh SO, et al. Effects of general and locoregional anesthesia on reproductive outcome for in vitro fertilization: a meta-analysis. J Korean Med Sci. 2000;15(1):68-72. Full Text: Exclude Q3-Review article. [pmid: 10719812].
Kissin DM, Schieve LA, Reynolds MA. Multiple-birth risk associated with IVF and extended embryo culture: USA, 2001. Hum Reprod. 2005;20(8):2215-23. Full Text: Exclude Q4-No outcomes of interest; Full Text: Exclude Q3-Not RCT. [pmid: 15831506].
Kitamura S, Sugiyama T, Iida E, et al. A new hysteroscopic tubal embryo transfer catheter: development and clinical application. J Obstet Gynaecol Res. 2001;27(5):281-4. Full Text: Exclude Q3-Not RCT. [pmid: 11776511].
Kjellberg AT, Carlsson P, Bergh C. Randomized single versus double embryo transfer: obstetric and paediatric outcome and a cost-effectiveness analysis. Hum Reprod. 2006;21(1):210-6. Full Text: Exclude Q4-Results stratified by treatment, not single vs. twin. [pmid: 16172148].
Klemetti R, Sevon T, Gissler M, et al. Complications of IVF and ovulation induction. Hum Reprod. 2005;20(12):3293-300. Full Text: Exclude Q3-Not RCT; Full Text: Exclude Q2-Not RCT. [pmid: 16126753].
Klonoff-Cohen H, Natarajan L. The concerns during assisted reproductive technologies (CART) scale and pregnancy outcomes. Fertil Steril. 2004;81(4):982-8. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 15066452].
Kocak I, Ustun C. Effects of metformin on insulin resistance, androgen concentration, ovulation and pregnancy rates in women with polycystic ovary syndrome following laparoscopic ovarian drilling. J Obstet Gynaecol Res. 2006;32(3):292-8. Full Text: Exclude Q2-Not RCT. [pmid: 16764619].
Kolibianakis E, Zikopoulos K, Albano C, et al. Reproductive outcome of polycystic ovarian syndrome patients treated with GnRH antagonists and recombinant FSH for IVF/ICSI. Reproductive Biomedicine Online. 2003;7(3):313-8. Full Text: Exclude Q3-Not RCT. [pmid: 14653891].
Kolibianakis EM, Zikopoulos K, Smitz J, et al. Administration of gonadotropin-releasing hormone antagonist from day 1 of stimulation in in vitro fertilization. Fertil Steril. 2004;82(1):223-6. Full Text: Exclude Q2-Not RCT; Full Text: Exclude Q3-Not RCT. [pmid: 15237018].
Komori S, Kasumi H, Horiuchi I, et al. Prevention of multiple pregnancies by restricting the number of transferred embryos: randomized control study. Arch Gynecol Obstet. 2004;270(2):91-3. Full Text: Exclude Q3-Data not per patient. [pmid: 12908110].
Konc J, Kanyo K, Cseh S. Deliveries from embryos fertilized with spermatozoa obtained from cryopreserved testicular tissue. J Assist Reprod Genet. 2006;23(5):247-52. Full Text: Exclude Q3-Not RCT. [pmid: 16786419].
Kosasa TS, McNamee PI, Morton C, et al. Pregnancy rates after transfer of cryopreserved blastocysts cultured in a sequential media. Am J Obstet Gynecol. 2005;192(6):2035-9. discussion 2039–40. Full Text: Exclude Q3-Not RCT. [pmid: 15970888].
Kosmas IP, Tatsioni A, Fatemi HM, et al. Human chorionic gonadotropin administration vs. luteinizing monitoring for intrauterine insemination timing, after administration of clomiphene citrate: a meta-analysis. Fertil Steril. 2007;87(3):607-12. Full Text: Exclude Q2-Review article. [pmid: 17173907].
Kousta E, White DM, Franks S. Modern use of clomiphene citrate in induction of ovulation. Hum Reprod Update. 1997;3(4):359-65. Full Text: Exclude Q2-Background article. [pmid: 9459281].
Kovacs G, MacLachlan V, Rombauts L, et al. Replacement of one selected embryo is just as successful as two embryo transfer, without the risk of twin pregnancy. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2003;43(5):369-71. Full Text: Exclude Q3-Not RCT. [pmid: 14717314].
Kovacs GT, Breheny S, Maclachlan V, et al. Outcome of pregnancies achieved by in vitro fertilisation techniques and diagnosed as twins at the 6 week ultrasound. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2004;44(6):510-3. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 15598286].
Kovacs P, Barg PE, Witt BR. Hypothalamic-pituitary suppression with oral contraceptive pills does not improve outcome in poor responder patients undergoing in vitro fertilization-embryo transfer cycles. J Assist Reprod Genet. 2001;18(7):391-4. Full Text: Exclude Q3-Not RCT. [pmid: 11499324].
Kovacs P, Matyas S, Bernard A, et al. Comparison of clinical outcome and costs with CC + gonadotropins and gnrha + gonadotropins during Ivf/ICSI cycles. J Assist Reprod Genet. 2004;21(6):197-202. Full Text: Exclude Q3-Not RCT. [pmid: 15526974].
Kovo M, Weissman A, Gur D, et al. Neonatal outcome in polycystic ovarian syndrome patients treated with metformin during pregnancy. Journal of Maternal-Fetal & Neonatal Medicine. 2006;19(7):415-9. Full Text: Exclude-Not relevant to any question. [pmid: 16923696].
Krause BT, Ohlinger R. Safety and efficacy of low dose hCG for luteal support after triggering ovulation with a GnRH agonist in cases of polyfollicular development. Eur J Obstet Gynecol Reprod Biol. 2006;126(1):87-92. Full Text: Exclude Q3-No relevant outcomes. [pmid: 16377065].
Kuczynski W, Dhont M, Grygoruk C, et al. The outcome of intracytoplasmic injection of fresh and cryopreserved ejaculated spermatozoa—a prospective randomized study. Hum Reprod. 2001;16(10):2109-13. Full Text: Exclude Q3-Male. [pmid: 11574500].
Kuczynski W, Dhont M, Grygoruk C, et al. Rescue ICSI of unfertilized oocytes after IVF. Hum Reprod. 2002;17(9):2423-7. Full Text: Exclude Q3-Not RCT. [pmid: 12202435].
Kung FT, Chang SY, Yang CY, et al. Transfer of nonselected transferable day 3 embryos in low embryo producers. Fertil Steril. 2003;80(6):1364-70. Full Text: Exclude Q3-Not RCT. [pmid: 14667870].
Kupker W, Schlegel PN, Al-Hasani S, et al. Use of frozen-thawed testicular sperm for intracytoplasmic sperm injection. Fertil Steril. 2000;73(3):453-8. Full Text: Exclude Q3-Not RCT. [pmid: 10688995].
Kwan I, Bhattacharya S, Knox F, et al. Conscious sedation and analgesia for oocyte retrieval during in vitro fertilisation procedures [Full Review]. Cochrane Database of Systematic Reviews 2005, Issue 3. Art. No.: CD004829. DOI: 10.1002/14651858.CD004829.pub2. Full Text: Exclude Q3-Review article (Cochrane).
Kwan I, Bhattacharya S, Knox F, et al. Conscious sedation and analgesia for oocyte retrieval during IVF procedures: a Cochrane review. Hum Reprod. 2006;21(7):1672-9. Full Text: Exclude Q3-Review article. [pmid: 16818961].
Kwee J, Schats R, McDonnell J, et al. The clomiphene citrate challenge test versus the exogenous follicle-stimulating hormone ovarian reserve test as a single test for identification of low responders and hyperresponders to in vitro fertilization. Fertil Steril. 2006;85(6):1714-22. Full Text: Exclude Q3-No relevant outcomes. [pmid: 16650416].
La Sala GB, Nucera G, Gallinelli A, et al. Lower embryonic loss rates among twin gestations following assisted reproduction. J Assist Reprod Genet. 2005;22(5):181-4. Full Text: Exclude Q3-Not RCT. [pmid: 16047578].
La Sala GB, Villani MT, Nicoli A, et al. Effect of the mode of assisted reproductive technology conception on obstetric outcomes for survivors of the vanishing twin syndrome. Fertil Steril. 2006;86(1):247-9. Full Text: Exclude Q4-Data inconsistent. [pmid: 16716323].
Lahav-Baratz S, Koifman M, Shiloh H, et al. Analyzing factors affecting the success rate of frozen-thawed embryos. J Assist Reprod Genet. 2003;20(11):444-8. Full Text: Exclude Q3-Not RCT. [pmid: 14714822].
Lahav-Baratz S, Rothschild E, Grach B, et al. The value of sperm pooling and cryopreservation in patients with transient azoospermia or severe oligoasthenoteratozoospermia. Hum Reprod. 2002;17(1):157-60. Full Text: Exclude Q3-Not RCT. [pmid: 11756381].
Lai TH, Chen SC, Tsai MS, et al. First-trimester screening for Down syndrome in singleton pregnancies achieved by intrauterine insemination. J Assist Reprod Genet. 2003;20(8):327-31. Full Text: Exclude-Not relevant to any question. [pmid: 12948096].
Lainas T, Petsas G, Stavropoulou G, et al. Administration of methylprednisolone to prevent severe ovarian hyperstimulation syndrome in patients undergoing in vitro fertilization. Fertil Steril. 2002;78(3):529-33. Full Text: Exclude Q2-Not RCT. [pmid: 12215328].
Lam R, Ma S, Robinson WP, et al. Cytogenetic investigation of fetuses and infants conceived through intracytoplasmic sperm injection. Fertil Steril. 2001;76(6):1272-5. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 11730766].
Lamas C, Chambry J, Nicolas I, et al. Alexithymia in infertile women. Journal of Psychosomatic Obstetrics & Gynecology. 2006;27(1):23-30. Full Text: Exclude-Not relevant to any question. [pmid: 16752873].
Lanzendorf SE, Ratts VS, Moley KH, et al. A randomized, prospective study comparing laser-assisted hatching and assisted hatching using acidified medium. Fertil Steril. 2007;87(6):1450-7. Full Text: Exclude Q3-Crossover design, no 1st period data. [pmid: 17207801].
Lass A, McVeigh E. UK Gonal-f FbM PMS Group. Routine use of r-hFSH follitropin alfa filled-by-mass for follicular development for IVF: a large multicentre observational study in the UK. Reproductive Biomedicine Online. 2004;9(6):604-10. Full Text: Exclude Q3-Not RCT. [pmid: 15670403].
Lathi RB, Milki AA. Rate of aneuploidy in miscarriages following in vitro fertilization and intracytoplasmic sperm injection. Fertil Steril. 2004;81(5):1270-2. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 15136088].
Lawson R, El-Toukhy T, Kassab A, et al. Poor response to ovulation induction is a stronger predictor of early menopause than elevated basal FSH: a life table analysis. Hum Reprod. 2003;18(3):527-33. Full Text: Exclude-Not relevant to any question. [pmid: 12615819].
Ledger WL, Anumba D, Marlow N, et al. The costs to the NHS of multiple births after IVF treatment in the UK. BJOG. 2006;113(1):21-5. Full Text: Exclude Q4-No outcomes of interest. [pmid: 16398766].
Lee C, Mak FS, Keith J, et al. A retrospective review comparing the use of Gonal-F and Metrodin-HP for in-vitro fertilisation (IVF). Med J Malaysia. 2003;58(1):94-8. Full Text: Exclude Q3-Not RCT. [pmid: 14556331].
Legro RS, Barnhart HX, Schlaff WD, et al. Clomiphene, metformin, or both for infertility in the polycystic ovary syndrome. N Engl J Med. 2007;356(6):551-66. Full Text: Exclude Q4-No pregnancy outcome; Full Text: Include Q2. [pmid: 17287476].
Legro RS, Myers E. Surrogate end-points or primary outcomes in clinical trials in women with polycystic ovary syndrome?. Hum Reprod. 2004;19(8):1697-704. Full Text: Exclude Q2-Background article. [pmid: 15192061].
Lenton E, Mohamed K. Optimizing assisted reproduction: impact of low-dose gonadotropin-releasing hormone agonist on in vitro fertilization outcome. Fertil Steril. 2005;84(6):1783-5. Full Text: Exclude Q3-Not RCT. [pmid: 16359992].
Lenton EA. Stimulated intrauterine insemination: efficient, cost-effective, safe?. Human Fertility. 2004;7(4):253-65. Full Text: Exclude Q2-Not RCT. [pmid: 15621890].
Lerner-Geva L, Geva E, Lessing JB, et al. The possible association between in vitro fertilization treatments and cancer development. Int J Gynecol Cancer. 2003;13(1):23-7. Full Text: Exclude Q2-Not RCT; Full Text: Include Q4. [pmid: 12631215].
Letterie G, Marshall L, Angle M. The relationship of clinical response, oocyte number, and success in oocyte donor cycles. J Assist Reprod Genet. 2005;22(3):115-7. Full Text: Exclude Q3-Not RCT. [pmid: 16018241].
Levi AJ, Drews MR, Bergh PA, et al. Controlled ovarian hyperstimulation does not adversely affect endometrial receptivity in in vitro fertilization cycles. Fertil Steril. 2001;76(4):670-4. Full Text: Exclude Q3-Not RCT. [pmid: 11591397].
Levi R, Kupelioglu L, Ozcakyr HT, et al. Complete down-regulation is not mandatory for good assisted reproductive treatment cycle outcomes. Eur J Obstet Gynecol Reprod Biol. 2003;111(1):55-8. Full Text: Exclude Q3-Not RCT. [pmid: 14557012].
Levran D, Farhi J, Nahum H, et al. Prospective evaluation of blastocyst stage transfer vs. zygote intrafallopian tube transfer in patients with repeated implantation failure. Fertil Steril. 2002;77(5):971-7. Full Text: Exclude Q3-Not RCT. [pmid: 12009353].
Liao AW, Heath V, Kametas N, et al. First-trimester screening for trisomy 21 in singleton pregnancies achieved by assisted reproduction. Hum Reprod. 2001;16(7):1501-4. Full Text: Exclude Q4-No pregnancy outcome. [pmid: 11425838].
Licciardi F, Berkeley AS, Krey L, et al. A two- versus three-embryo transfer: the oocyte donation model. Fertil Steril. 2001;75(3):510-3. Full Text: Exclude Q3-Not RCT. [pmid: 11239533].
Lin PC, D'Amico JF, Nakajima ST. Initial experience with a modification of the follicle aspiration, sperm injection, and assisted rupture technique. Fertil Steril. 2000;73(4):855-8. Full Text: Exclude Q3-Not RCT. [pmid: 10731553].
Lintsen AM, Pasker-de Jong PC, de Boer EJ, et al. Effects of subfertility cause, smoking and body weight on the success rate of IVF. Hum Reprod. 2005;20(7):1867-75. Full Text: Exclude Q3-Not RCT. [pmid: 15817580].
Lisi F, Rinaldi L, Fishel S, et al. Evaluation of two doses of recombinant luteinizing hormone supplementation in an unselected group of women undergoing follicular stimulation for in vitro fertilization. Fertil Steril. 2005;83(2):309-15. Full Text: Exclude Q3-Not RCT. [pmid: 15705367].
Lisi F, Rinaldi L, Fishel S, et al. Use of recombinant LH in a group of unselected IVF patients. Reproductive Biomedicine Online. 2002;5(2):104-8. Full Text: Exclude Q3-Not RCT. [pmid: 12419032].
Little SE, Ratcliffe J, Caughey AB. Cost of transferring one through five embryos per in vitro fertilization cycle from various payor perspectives. Obstet Gynecol. 2006;108(3 Pt 1):593-601. Full Text: Exclude Q3-Not RCT. [pmid: 16946220].
Liu W, Gong F, Luo K, et al. Comparing the pregnancy rates of one versus two intrauterine inseminations (IUIs) in male factor and idiopathic infertility. J Assist Reprod Genet. 2006;23(2):75-9. Full Text: Exclude-Not relevant to any question. [pmid: 16496208].
Lodhi S, Abdel Fattah A, Abozaid T, et al. Gamete intra-fallopian transfer or intrauterine insemination after controlled ovarian hyperstimulation for treatment of infertility due to endometriosis. Gynecol Endocrinol. 2004;19(3):152-9. Full Text: Exclude Q3-Not RCT. [pmid: 15697077].
Lord JM, Flight IHK, Norman RJ. Insulin-sensitising drugs (metformin, troglitazone, rosiglitazone, pioglitazone, D-chiro-inositol) for polycystic ovary syndrome [Full Review]. Cochrane Database of Systematic Reviews 2003, Issue 2. Art. No.: CD003053. DOI: 10.1002/14651858.CD003053. Full Text: Exclude Q2-Review article (Cochrane)
Loutradis D, Stefanidis K, Drakakis P, et al. Comparison between “short” and “long” protocols in an ICSI programme. Eur J Obstet Gynecol Reprod Biol. 2005;120(1):69-72. Full Text: Exclude Q3-Not RCT; Full Text: Exclude Q2-Not RCT. [pmid: 15866089].
Ludwig M, Katalinic A, Diedrich K. Use of GnRH antagonists in ovarian stimulation for assisted reproductive technologies compared to the long protocol. Meta-analysis. Arch Gynecol Obstet. 2001;265(4):175-82. Full Text: Exclude Q3-Review article. [pmid: 11789740].
Ludwig M, Riethmuller-Winzen H, Felberbaum RE, et al. Health of 227 children born after controlled ovarian stimulation for in vitro fertilization using the luteinizing hormone-releasing hormone antagonist cetrorelix. Fertil Steril. 2001;75(1):18-22. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 11163811].
Ludwig M, Schopper B, Katalinic A, et al. Experience with the elective transfer of two embryos under the conditions of the german embryo protection law: results of a retrospective data analysis of 2573 transfer cycles. Hum Reprod. 2000;15(2):319-24. Full Text: Exclude Q3-Not RCT. [pmid: 10655302].
Lukassen HG, Braat DD, Wetzels AM, et al. Two cycles with single embryo transfer versus one cycle with double embryo transfer: a randomized controlled trial. Hum Reprod. 2005;20(3):702-8. Full Text: Exclude Q4-No relevant data; Full Text: Include Q3. [pmid: 15618254].
Lurie D, Check JH, Nazari A, et al. Cumulative pregnancy rates after four embryo transfers of either fresh or frozen embryos. Clin Exp Obstet Gynecol. 2001;28(3):148-52. Full Text: Exclude Q3-Not RCT. [pmid: 11530861].
Lyerly AD, Steinhauser K, Namey E, et al. Factors that affect infertility patients' decisions about disposition of frozen embryos. Fertil Steril. 2006;85(6):1623-30. Full Text: Exclude-Not relevant to any question. [pmid: 16678178].
Ma S, Yuen BH. Intracytoplasmic sperm injection could minimize the incidence of prematurely condensed human sperm chromosomes. Fertil Steril. 2001;75(6):1095-101. Full Text: Exclude Q3-Not RCT. [pmid: 11384632].
Madankumar R, Tsang J, Lesser ML, et al. Clomiphene citrate induced ovulation and intrauterine insemination: effect of timing of human chorionic gonadotropin injection in relation to the spontaneous LH surge on pregnancy rates. J Assist Reprod Genet. 2005;22(4):155-9. Full Text: Exclude Q2-Not RCT. [pmid: 16021859].
Mahani IM, Afnan M. The pregnancy rates with intrauterine insemination (IUI) in superovulated cycles employing different protocols (clomiphen citrate (CC), human menopausal gonadotropin (HMG) and HMG+CC) and in natural ovulatory cycle. JPMA J Pak Med Assoc. 2004;54(10):503-5. Full Text: Exclude Q2-Not RCT. [pmid: 15552282].
Makhseed M, Al Salem MH, Ahmed MA. Percutaneous testicular sperm aspiration and intracytoplasmic sperm injection in obstructive and non-obstructive azoospermia: an easy alternative to TESE and MESA. Urol Int. 2002;68(2):86-90. Full Text: Exclude Q3-Not RCT. [pmid: 11834896].
Malcolm CE, Cumming DC. Follow-up of infertile couples who dropped out of a specialist fertility clinic. Fertil Steril. 2004;81(2):269-70. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 14967354].
Malkawi HY, Qublan HS, Hamaideh AH. Medical vs. surgical treatment for clomiphene citrate-resistant women with polycystic ovary syndrome. Journal of Obstetrics & Gynaecology. 2003;23(3):289-93. Full Text: Exclude Q3-Not RCT. [pmid: 12850864].
Mansour R, Aboulghar M, Serour GI, et al. The use of clomiphene citrate/human menopausal gonadotrophins in conjunction with GnRH antagonist in an IVF/ICSI program is not a cost effective protocol. Acta Obstet Gynecol Scand. 2003;82(1):48-52. Full Text: Exclude Q2-Not RCT. [pmid: 12580839].
Mansour RT, Aboulghar MA, Serour GI, et al. The use of gonadotropin-releasing hormone antagonist in a flexible protocol: a pilot study. Am J Obstet Gynecol. 2003;189(2):444-6. Full Text: Exclude Q3-Not RCT. [pmid: 14520215].
Mansour RT, Rhodes CA, Aboulghar MA, et al. Transfer of zona-free embryos improves outcome in poor prognosis patients: a prospective randomized controlled study. Hum Reprod. 2000;15(5):1061-4. Full Text: Exclude Q3-Not RCT. [pmid: 10783352].
Marci R, Senn A, Dessole S, et al. A low-dose stimulation protocol using highly purified follicle-stimulating hormone can lead to high pregnancy rates in in vitro fertilization patients with polycystic ovaries who are at risk of a high ovarian response to gonadotropins. Fertil Steril. 2001;75(6):1131-5. Full Text: Exclude Q3-Not RCT. [pmid: 11384638].
Margreiter M, Weghofer A, Kogosowski A, et al. A prospective randomized multicenter study to evaluate the best day for embryo transfer: does the outcome justify prolonged embryo culture?. J Assist Reprod Genet. 2003;20(2):91-4. Full Text: Exclude Q3-No 2×2 table. [pmid: 12688593].
Marrs RP, Greene J, Stone BA. Potential factors affecting embryo survival and clinical outcome with cryopreserved pronuclear human embryos. Am J Obstet Gynecol. 2004;190(6):1766-71. discussion 1771–2. Full Text: Exclude-Not relevant to any question. [pmid: 15284794].
Martikainen H, Orava M, Lakkakorpi J, et al. Day 2 elective single embryo transfer in clinical practice: better outcome in ICSI cycles. Hum Reprod. 2004;19(6):1364-6. Full Text: Exclude Q3-Not RCT. [pmid: 15105390].
Martikainen H, Tiitinen A, Tomas C, et al. One versus two embryo transfer after IVF and ICSI: a randomized study. Hum Reprod. 2001;16(9):1900-3. Full Text: Exclude Q3-Data not per patient. [pmid: 11527895].
Martinez F, Boada M, Coroleu B, et al. A prospective trial comparing oocyte donor ovarian response and recipient pregnancy rates between suppression with gonadotrophin-releasing hormone agonist (GnRHa) alone and dual suppression with a contraceptive vaginal ring and GnRH. Hum Reprod. 2006;21(8):2121-5. Full Text: Exclude Q3-Donor egg. [pmid: 16632462].
Mathur R, Hayman G, Bansal A, et al. Serum vascular endothelial growth factor levels are poorly predictive of subsequent ovarian hyperstimulation syndrome in highly responsive women undergoing assisted conception. Fertil Steril. 2002;78(6):1154-8. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 12477503].
Matorras R, Corcostegui B, Mendoza R, et al. Converting an IVF cycle to IUI in low responders with at least 2 follicles. J Reprod Med. 2003;48(10):789-91. Full Text: Exclude Q2-Not RCT; Full Text: Exclude Q3-Not RCT. [pmid: 14619646].
Matorras R, Diaz T, Corcostegui B, et al. Ovarian stimulation in intrauterine insemination with donor sperm: a randomized study comparing clomiphene citrate in fixed protocol versus highly purified urinary FSH. Hum Reprod. 2002;17(8):2107-11. Full Text: Exclude Q2-Donor sperm. [pmid: 12151445].
Matorras R, Mendoza R, Exposito A, et al. Influence of the time interval between embryo catheter loading and discharging on the success of IVF. Hum Reprod. 2004;19(9):2027-30. Full Text: Exclude Q3-Not RCT. [pmid: 15192071].
Mau Kai C, Main KM, Andersen AN, et al. Reduced serum testosterone levels in infant boys conceived by intracytoplasmic sperm injection. J Clin Endocrinol Metab. 2007;92(7):2598-603. Full Text: Exclude Q4-Lab results only, no clinical correlation. [pmid: 17456568].
Mavrides A, Lavery S, Trew G. New protocol for commencing the GnRH antagonist in assisted conception treatment cycles: elimination of the premature LH surge with similar pregnancy rates. Reprod Nutr Dev. 2004;44(6):565-70. Full Text: Exclude Q3-Not RCT. [pmid: 15762300].
Mayer A, Lunenfeld E, Wiznitzer A, et al. Increased prevalence of gestational diabetes mellitus in in vitro fertilization pregnancies inadvertently conceived during treatment with long-acting triptorelin acetate. Fertil Steril. 2005;84(3):789-92. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 16169427].
Maymon R, Shulman A. Comparison of triple serum screening and pregnancy outcome in oocyte donation versus IVF pregnancies. Hum Reprod. 2001;16(4):691-5. Full Text: Exclude Q3-Not RCT; Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 11278220].
McDonald S, Murphy K, Beyene J, et al. Perinatal outcomes of in vitro fertilization twins: a systematic review and meta-analyses. Am J Obstet Gynecol. 2005;193(1):141-52. Full Text: Exclude Q4-Review article. [pmid: 16021072].
McDonald SD, Murphy K, Beyene J, et al. Perinatel outcomes of singleton pregnancies achieved by in vitro fertilization: a systematic review and meta-analysis. J Obstet Gynaecol Can. 2005;27(5):449-59. Full Text: Exclude Q4-Review article. [pmid: 16100639].
McGovern PG, Llorens AJ, Skurnick JH, et al. Increased risk of preterm birth in singleton pregnancies resulting from in vitro fertilization-embryo transfer or gamete intrafallopian transfer: a meta-analysis. Fertil Steril. 2004;82(6):1514-20. Full Text: Exclude Q4-Review article. [pmid: 15589852].
Menezo Y, Barak Y. Comparison between day-2 embryos obtained either from ICSI or resulting from short insemination IVF: influence of maternal age. Hum Reprod. 2000;15(8):1776-80. Full Text: Exclude Q3-Not RCT. [pmid: 10920102].
Meng MV, Greene KL, Turek PJ. Surgery or assisted reproduction? A decision analysis of treatment costs in male infertility. J Urol. 2005;174(5):1926-31. discussion 1931. Full Text: Exclude Q3-Not RCT. [pmid: 16217347].
Mercader A, Garcia-Velasco JA, Escudero E, et al. Clinical experience and perinatal outcome of blastocyst transfer after coculture of human embryos with human endometrial epithelial cells: a 5-year follow-up study. Fertil Steril. 2003;80(5):1162-8. Full Text: Exclude Q3-Not RCT. [pmid: 14607568].
Meschede D, Lemcke B, Behre HM, et al. Non-reproductive heritable disorders in infertile couples and their first degree relatives. Hum Reprod. 2000;15(7):1609-12. Full Text: Exclude Q4-Not true case-control or cohort. [pmid: 10875875].
Midrio P, Nogare CD, Di Gianantonio E, et al. Are congenital anorectal malformations more frequent in newborns conceived with assisted reproductive techniques?. Reprod Toxicol. 2006;22(4):576-7. Full Text: Exclude Q4-Not true case-control or cohort. [pmid: 16815669].
Mikkelsen AL, Lindenberg S. Benefit of FSH priming of women with PCOS to the in vitro maturation procedure and the outcome: a randomized prospective study. Reproduction. 2001;122(4):587-92. Full Text: Exclude Q3-Data not per patient. [pmid: 11570966].
Milki AA, Hinckley MD, Behr B. Comparison of blastocyst transfer to day 3 transfer with assisted hatching in the older patient. Fertil Steril. 2002;78(6):1244-7. Full Text: Exclude Q3-Not RCT. [pmid: 12477519].
Milki AA, Jun SH, Hinckley MD, et al. Incidence of monozygotic twinning with blastocyst transfer compared to cleavage-stage transfer. Fertil Steril. 2003;79(3):503-6. Full Text: Exclude Q3-Not RCT. [pmid: 12620430].
Miller DC, Hollenbeck BK, Smith GD, et al. Processed total motile sperm count correlates with pregnancy outcome after intrauterine insemination. Urology. 2002;60(3):497-501. Full Text: Exclude Q2-Not RCT. [pmid: 12350496].
Miller PB, Acres ML, Proctor JG, et al. Flexible versus rigid intrauterine insemination catheters: a prospective, randomized, controlled study. Fertil Steril. 2005;83(5):1544-6. Full Text: Exclude-Not relevant to any question. [pmid: 15866596].
Milsom SR, Gibson G, Buckingham K, et al. Factors associated with pregnancy or miscarriage after clomiphene therapy in WHO group II anovulatory women. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2002;42(2):170-5. Full Text: Exclude Q2-Not RCT. [pmid: 12069145].
Min JK, Breheny SA, MacLachlan V, et al. What is the most relevant standard of success in assisted reproduction? The singleton, term gestation, live birth rate per cycle initiated: the BESST endpoint for assisted reproduction. Hum Reprod. 2004;19(1):3-7. Full Text: Exclude Q4-Data not per patient. [pmid: 14688149].
Min JK, Claman P, Hughes E, et al. Guidelines for the number of embryos to transfer following in vitro fertilization. J Obstet Gynaecol Can. 2006;28(9):799-813. Full Text: Exclude-Not relevant to any question. [pmid: 17022921].
Mirkin S, Jones EL, Mayer JF, et al. Impact of transabdominal ultrasound guidance on performance and outcome of transcervical uterine embryo transfer. J Assist Reprod Genet. 2003;20(8):318-22. Full Text: Exclude Q3-Not RCT. [pmid: 12948094].
Mitwally MF, Abdel-Razeq S, Casper RF. Human chorionic gonadotropin administration is associated with high pregnancy rates during ovarian stimulation and timed intercourse or intrauterine insemination. Reproductive Biology & Endocrinology. 2004;2(1):55. Full Text: Exclude Q3-Not RCT. [pmid: 15239837]. [pmcid: 479701].
Mitwally MF, Biljan MM, Casper RF. Pregnancy outcome after the use of an aromatase inhibitor for ovarian stimulation. Am J Obstet Gynecol. 2005;192(2):381-6. Full Text: Exclude Q2-Not RCT. [pmid: 15695975].
Moayeri SE, Behr B, Lathi RB, et al. Risk of monozygotic twinning with blastocyst transfer decreases over time: an 8-year experience. Fertil Steril. 2007;87(5):1028-32. Full Text: Exclude Q4-No controls. [pmid: 17343858].
Mochtar MH, Van der Veen F, Ziech M, et al. Recombinant Luteinizing Hormone (rLH) for controlled ovarian hyperstimulation in assisted reproductive cycles [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 2. Art. No.: CD005070. DOI: 10.1002/14651858.CD005070.pub2. Full Text: Exclude Q3-Review article (Cochrane).
Mohamed KA, Davies WA, Allsopp J, et al. Agonist “flare-up” versus antagonist in the management of poor responders undergoing in vitro fertilization treatment. Fertil Steril. 2005;83(2):331-5. Full Text: Exclude Q3-Not RCT. [pmid: 15705370].
Moon SY, Ku SY, Kim SM, et al. Clinical efficacy of the gonadotropin-releasing hormone antagonist, ganirelix, in Korean women undergoing controlled ovarian hyperstimulation for in vitro fertilization and embryo transfer with recombinant follicle-stimulating hormone. J Obstet Gynaecol Res. 2005;31(3):227-35. Full Text: Exclude Q3-Not RCT. [pmid: 15916659].
Moreno L, Diaz I, Pacheco A, et al. Extended coasting duration exerts a negative impact on IVF cycle outcome due to premature luteinization. Reproductive Biomedicine Online. 2004;9(5):500-4. Full Text: Exclude Q3-Not RCT. [pmid: 15588466].
Morshedi M, Duran HE, Taylor S, et al. Efficacy and pregnancy outcome of two methods of semen preparation for intrauterine insemination: a prospective randomized study. Fertil Steril. 2003;79(Suppl 3):1625-32. Full Text: Exclude-Not relevant to any question. [pmid: 12801569].
Mortimer D, French S. Can dissenting findings regarding the comparative effectiveness of ICSI and IVF be explained by a learning curve?. J Assist Reprod Genet. 2006;23(1):33-6. Full Text: Exclude Q3-No relevant outcomes. [pmid: 16429320].
Moser M, Ebner T, Sommergruber M, et al. Laser-assisted zona pellucida thinning prior to routine ICSI. Hum Reprod. 2004;19(3):573-8. Full Text: Exclude Q3-Not RCT. [pmid: 14998954].
Mukaida T, Nakamura S, Tomiyama T, et al. Vitrification of human blastocysts using cryoloops: clinical outcome of 223 cycles. Hum Reprod. 2003;18(2):384-91. Full Text: Exclude Q3-Not RCT. [pmid: 12571178].
Mulders AG, Laven JS, Eijkemans MJ, et al. Patient predictors for outcome of gonadotrophin ovulation induction in women with normogonadotrophic anovulatory infertility: a meta-analysis. Hum Reprod Update. 2003;9(5):429-49. Full Text: Exclude Q2-Review article. [pmid: 14640376].
Murray S, Shetty A, Rattray A, et al. A randomized comparison of alternative methods of information provision on the acceptability of elective single embryo transfer. Hum Reprod. 2004;19(4):911-6. Full Text: Exclude Q3-No pregnancy outcome. [pmid: 14990543].
Nagy ZP, Rienzi LF, Ubaldi FM, et al. Effect of reduced oocyte aging on the outcome of rescue intracytoplasmic sperm injection. Fertil Steril. 2006;85(4):901-6. Full Text: Exclude Q3-Not RCT. [pmid: 16580372].
Nargund G, Waterstone J, Bland J, et al. Cumulative conception and live birth rates in natural (unstimulated) IVF cycles. Hum Reprod. 2001;16(2):259-62. Full Text: Exclude Q3-Not RCT. [pmid: 11157816].
Narine LH, Vezmar M, Sutija VG, et al. Mode of conception, placental morphology and perinatal outcome of twin gestations. J Perinat Med. 2003;31(2):99-104. Full Text: Exclude Q4-No pregnancy outcome. [pmid: 12747224].
Negro R, Mangieri T, Coppola L, et al. Levothyroxine treatment in thyroid peroxidase antibody-positive women undergoing assisted reproduction technologies: a prospective study. Hum Reprod. 2005;20(6):1529-33. Full Text: Exclude Q2-Special population; Full Text: Exclude Q3-Special population. [pmid: 15878930].
Neithardt AB, Segars JH, Hennessy S, et al. Embryo afterloading: a refinement in embryo transfer technique that may increase clinical pregnancy. Fertil Steril. 2005;83(3):710-4. Full Text: Exclude Q3-Not RCT. [pmid: 15749502].
Neri QV, Tanaka N, Wang A, et al. Intracytoplasmic sperm injection. Accomplishments and qualms. Minerva Ginecol. 2004;56(3):189-96. Full Text: Exclude Q4-Unable to determine comparison groups. [pmid: 15258530].
Ness RB, Cramer DW, Goodman MT, et al. Infertility, fertility drugs, and ovarian cancer: a pooled analysis of case-control studies. Am J Epidemiol. 2002;155(3):217-24. Full Text: Exclude Q2-Not RCT; Full Text: Exclude Q4-Review article. [pmid: 11821246].
Nestler JE. Metformin for the treatment of the polycystic ovary syndrome. N Engl J Med. 2008;358(1):47-54. Full Text: Exclude Q2-Background article. [pmid: 18172174].
Neubourg DD, Mangelschots K, Van Royen E, et al. Impact of patients' choice for single embryo transfer of a top quality embryo versus double embryo transfer in the first IVF/ICSI cycle. Hum Reprod. 2002;17(10):2621-5. Full Text: Exclude Q3-Not RCT. [pmid: 12351538].
Newton CR, McBride J, Feyles V, et al. Factors affecting patients' attitudes toward single- and multiple-embryo transfer. Fertil Steril. 2007;87(2):269-78. Full Text: Exclude-Not relevant to any question. [pmid: 17097648].
Ng EH, Lau EY, Yeung WS, et al. Transfer of two embryos instead of three will not compromise pregnancy rate but will reduce multiple pregnancy rate in an assisted reproduction unit. J Obstet Gynaecol Res. 2001;27(6):329-35. Full Text: Exclude Q3-Not RCT. [pmid: 11794819].
Ng EH, Makkar G, Yeung WS, et al. A randomized comparison of three insemination methods in an artificial insemination program using husbands' semen. J Reprod Med. 2003;48(7):542-6. Full Text: Exclude Q3-Not IVF; Full Text: Include Q2. [pmid: 12953328].
Ng EH, Tang OS, Chui DK, et al. Comparison of two different doses of lignocaine used in paracervical block during oocyte collection in an IVF programme. Hum Reprod. 2000;15(10):2148-51. Full Text: Exclude-Not relevant to any question. [pmid: 11006189].
Nicopoullos JD, Gilling-Smith C, Almeida PA, et al. The results of 154 ICSI cycles using surgically retrieved sperm from azoospermic men. Hum Reprod. 2004;19(3):579-85. Full Text: Exclude Q3-Not RCT. [pmid: 14998955].
Nicopoullos JD, Ramsay JW, Gilling-Smith C, et al. Frozen embryos generated from surgically retrieved sperm from azoospermic men: are they clinically viable?. J Assist Reprod Genet. 2004;21(11):401-7. Full Text: Exclude Q3-Not RCT. [pmid: 15672953].
Nieto JJ, Crow J, Sundaresan M, et al. Ovarian epithelial dysplasia in relation to ovulation induction and nulliparity. Gynecol Oncol. 2001;82(2):344-9. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 11531291].
Nikolettos N, Al-Hasani S, Felberbaum R, et al. Comparison of cryopreservation outcome with human pronuclear stage oocytes obtained by the GnRH antagonist, cetrorelix, and GnRH agonists. Eur J Obstet Gynecol Reprod Biol. 2000;93(1):91-5. Full Text: Exclude Q3-Not RCT. [pmid: 11000511].
Nosarka S, Kruger T, Siebert I, et al. Luteal phase support in in vitro fertilization: meta-analysis of randomized trials. Gynecol Obstet Invest. 2005;60(2):67-74. Full Text: Exclude Q3-Review article. [pmid: 15785074].
Nugent D, Vandekerckhove P, Hughes E, et al. Gonadotrophin therapy for ovulation induction in subfertility associated with polycystic ovary syndrome [Full Review]. Cochrane Database of Systematic Reviews 2000, Issue 3. Art. No.: CD000410. DOI: 10.1002/14651858.CD000410. Full Text: Exclude Q2-Review article (Cochrane).
Nygren KG, Andersen AN. Assisted reproductive technology in Europe, 1997. Results generated from European registers by ESHRE. European IVF-Monitoring Programme (EIM), for the European Society of Human Reproduction and Embryology (ESHRE). Hum Reprod. 2001;16(2):384-91. Full Text: Exclude Q3-Not RCT. [pmid: 11157839].
Nygren KG, Andersen AN. Assisted reproductive technology in Europe, 1999. Results generated from European registers by ESHRE. Hum Reprod. 2002;17(12):3260-74. Full Text: Exclude Q3-Not RCT. [pmid: 12456634].
Nygren KG, Andersen AN. European IVF-monitoring programme (EIM). European IVF-monitoring programme (EIM). Assisted reproductive technology in Europe, 1998. Results generated from European registers by ESHRE. European Society of Human Reproduction and Embryology.[erratum appears in Hum Reprod. 2002 Oct;17(10):2781.]. Hum Reprod. 2001;16(11):2459-71. Full Text: Exclude Q3-Not RCT. [pmid: 11679538].
O'Brien JH, Bowles B, Kamal KM, et al. Microsurgical varicocelectomy for infertile couples with advanced female age: natural history in the era of ART. J Androl. 2004;25(6):939-43. Full Text: Exclude Q3-Not RCT. [pmid: 15477367].
Oakley L, Doyle P. Predicting the impact of in vitro fertilisation and other forms of assisted conception on perinatal and infant mortality in England and Wales: examining the role of multiplicity. BJOG. 2006;113(6):738-41. Full Text: Exclude-Not relevant to any question. [pmid: 16709220].
Oatway C, Gunby J, Daya S. Day three versus day two embryo transfer following in vitro fertilization or intracytoplasmic sperm injection [Full Review]. Cochrane Database of Systematic Reviews 2004, Issue 2. Art. No.: CD004378. DOI: 10.1002/14651858.CD004378.pub2. Full Text: Exclude Q3-Review article (Cochrane).
Oktay K, Buyuk E, Libertella N, et al. Fertility preservation in breast cancer patients: a prospective controlled comparison of ovarian stimulation with tamoxifen and letrozole for embryo cryopreservation. J Clin Oncol. 2005;23(19):4347-53. Full Text: Exclude-Not relevant to any question. [pmid: 15824416].
Ola B, Li TC. Implantation failure following in-vitro fertilization. Curr Opin Obstet Gynecol. 2006;18(4):440-5. Full Text: Exclude Q4-Background article. [pmid: 16794426].
Olivennes F, Mannaerts B, Struijs M, et al. Perinatal outcome of pregnancy after GnRH antagonist (ganirelix) treatment during ovarian stimulation for conventional IVF or ICSI: a preliminary report. Hum Reprod. 2001;16(8):1588-91. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 11473947].
Olivius K, Friden B, Lundin K, et al. Cumulative probability of live birth after three in vitro fertilization/intracytoplasmic sperm injection cycles. Fertil Steril. 2002;77(3):505-10. Full Text: Exclude Q3-Not RCT. [pmid: 11872203].
Olshansky E, Sereika S. The transition from pregnancy to postpartum in previously infertile women: a focus on depression. Arch Psychiatr Nurs. 2005;19(6):273-80. Full Text: Exclude Q4-No controls. [pmid: 16308127].
Ombelet W, Cadron I, Gerris J, et al. Obstetric and perinatal outcome of 1655 ICSI and 3974 IVF singleton and 1102 ICSI and 2901 IVF twin births: a comparative analysis. Reproductive Biomedicine Online. 2005;11(1):76-85. Full Text: Exclude Q3-Not RCT. [pmid: 16102293].
Ombelet W, Camus M, de Catte L. Relative contribution of ovarian stimulation versus in vitro fertilization and intracytoplasmic sperm injection to multifetal pregnancies requiring reduction to twins. Fertil Steril. 2007;88(4):997-9. Full Text: Exclude Q4-No outcomes data. [pmid: 17681333].
Ombelet W, Peeraer K, De Sutter P, et al. Perinatal outcome of ICSI pregnancies compared with a matched group of natural conception pregnancies in Flanders (Belgium): a cohort study. Reproductive Biomedicine Online. 2005;11(2):244-53. Full Text: Exclude Q3-Not RCT. [pmid: 16168226].
Opsahl MS, Blauer KL, Black SH, et al. The number of embryos available for transfer predicts successful pregnancy outcome in women over 39 years with normal ovarian hormonal reserve testing. J Assist Reprod Genet. 2001;18(10):551-6. Full Text: Exclude Q3-Not RCT. [pmid: 11699127].
Ortega-Gonzalez C, Cardoza L, Coutino B, et al. Insulin sensitizing drugs increase the endogenous dopaminergic tone in obese insulin-resistant women with polycystic ovary syndrome. J Endocrinol. 2005;184(1):233-9. Full Text: Exclude Q2-No pregnancy outcome. [pmid: 15642799].
Orvieto R, Ben-Rafael Z, Ashkenazi J, et al. Outcome of pregnancies derived from assisted reproductive technologies: IVF versus ICSI. J Assist Reprod Genet. 2000;17(7):385-7. Full Text: Exclude Q4-Data inconsistent. [pmid: 11077619].
Orvieto R, Meltcer S, Volodarski M, et al. Luteal phase support for patients undergoing frozen-thawed embryo transfer cycles—the required progesterone dose. Clin Exp Obstet Gynecol. 2007;34(1):25-6. Full Text: Exclude Q3-Not RCT. [pmid: 17447632].
Osmanagaoglu K, Kolibianakis E, Tournaye H, et al. Cumulative live birth rates after transfer of cryopreserved ICSI embryos. Reproductive Biomedicine Online. 2004;8(3):344-8. Full Text: Exclude Q3-Not RCT. [pmid: 15038902].
Owj M, Tehrani-Nejad ES, Amirchaghmaghi E, et al. The role of ketoconazole in the prevention of ovarian hyperstimulation syndrome in patients with polycystic ovary syndrome during assisted reproductive technology cycles. Saudi Medical Journal. 2005;26(10):1584-7. Full Text: Exclude Q3-No pregnancy outcome. [pmid: 16228060].
Ozturk O, Templeton A. In-vitro fertilisation and risk of multiple pregnancy. Lancet. 2002;359(9302):232. Full Text: Exclude Q3-Not RCT. [pmid: 11812563].
Pabuccu R, Onalan G, Goktolga U, et al. Aspiration of ovarian endometriomas before intracytoplasmic sperm injection. Fertil Steril. 2004;82(3):705-11. Full Text: Exclude Q3-Not RCT. [pmid: 15374718].
Palermo GD, Neri QV, Hariprashad JJ, et al. ICSI and its outcome. Seminars in Reproductive Medicine. 2000;18(2):161-9. Full Text: Exclude Q4-Data not per patient. [pmid: 11256166].
Palermo GD, Takeuchi T, Neri QV, et al. Application of intracytoplasmic sperm injection in assisted reproductive technologies. Reproductive Biomedicine Online. 2003;6(4):456-63. Full Text: Exclude Q4-Response rate in controls < 15%. [pmid: 12831594].
Palomba S, Orio F Jr, Falbo A, et al. Plasminogen activator inhibitor 1 and miscarriage after metformin treatment and laparoscopic ovarian drilling in patients with polycystic ovary syndrome. Fertil Steril. 2005;84(3):761-5. Full Text: Exclude Q2-No pregnancy outcome. [pmid: 16169420].
Pan H, Li YY, Li TC, et al. Increased (CTG/CAG)(n) lengths in myotonic dystrophy type 1 and Machado-Joseph disease genes in idiopathic azoospermia patients. Hum Reprod. 2002;17(6):1578-83. Full Text: Exclude Q4-No pregnancy outcome. [pmid: 12042281].
Pan PD, Peter I, Lambert-Messerlian GM, et al. Cell-free fetal DNA levels in pregnancies conceived by IVF. Hum Reprod. 2005;20(11):3152-6. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 16006472].
Panagopoulou E, Vedhara K, Gaintarzti C, et al. Emotionally expressive coping reduces pregnancy rates in patients undergoing in vitro fertilization. Fertil Steril. 2006;86(3):672-7. Full Text: Exclude Q3-Not RCT. [pmid: 16859690].
Pandian Z, Templeton A, Serour G, et al. Number of embryos for transfer after IVF and ICSI: a Cochrane review. Hum Reprod. 2005;20(10):2681-7. Full Text: Exclude Q3-Review article (Cochrane). [pmid: 16183994].
Pantos K, Stavrou D, Pichos I, et al. The successful use of hatched blastocysts in assisted reproductive technology. Clin Exp Obstet Gynecol. 2001;28(2):113-7. Full Text: Exclude Q3-Not RCT. [pmid: 11491370].
Pantos K, Stefanidis K, Pappas K, et al. Cryopreservation of embryos, blastocysts, and pregnancy rates of blastocysts derived from frozen-thawed embryos and frozen-thawed blastocysts. J Assist Reprod Genet. 2001;18(11):579-82. Full Text: Exclude Q3-Not RCT. [pmid: 11804424].
Papageorgiou TC, Guibert J, Savale M, et al. Low dose recombinant FSH treatment may reduce multiple gestations caused by controlled ovarian hyperstimulation and intrauterine insemination. BJOG. 2004;111(11):1277-82. Full Text: Exclude Q3-Not RCT. [pmid: 15521875].
Papaleo E, Doldi N, De Santis L, et al. Cabergoline influences ovarian stimulation in hyperprolactinaemic patients with polycystic ovary syndrome. Hum Reprod. 2001;16(11):2263-6. Full Text: Exclude Q2-Not RCT. [pmid: 11679501].
Park YS, Lee SH, Song SJ, et al. Influence of motility on the outcome of in vitro fertilization/intracytoplasmic sperm injection with fresh vs. frozen testicular sperm from men with obstructive azoospermia. Fertil Steril. 2003;80(3):526-30. Full Text: Exclude Q3-Not RCT. [pmid: 12969692].
Parsanezhad ME, Alborzi S, Motazedian S, et al. Use of dexamethasone and clomiphene citrate in the treatment of clomiphene citrate-resistant patients with polycystic ovary syndrome and normal dehydroepiandrosterone sulfate levels: a prospective, double-blind, placebo-controlled trial. Fertil Steril. 2002;78(5):1001-4. Full Text: Exclude Q2-Not RCT. [pmid: 12413984].
Parsanezhad ME, Alborzi S, Namavar Jahromi B. A prospective, double-blind, randomized, placebo-controlled clinical trial of bromocriptin in clomiphene-resistant patients with polycystic ovary syndrome and normal prolactin level. Arch Gynecol Obstet. 2004;269(2):125-9. Full Text: Exclude Q2-Not infertility study. [pmid: 14648180].
Pasqualotto FF, Rossi LM, Guilherme P, et al. Etiology-specific outcomes of intracytoplasmic sperm injection in azoospermic patients. Fertil Steril. 2005;83(3):606-11. Full Text: Exclude Q3-Not RCT. [pmid: 15749488].
Patrizio P, Bianchi V, Lalioti MD, et al. High rate of biological loss in assisted reproduction: it is in the seed, not in the soil. Reproductive Biomedicine Online. 2007;14(1):92-5. Full Text: Exclude-Not relevant to any question. [pmid: 17207339].
Pelinck MJ, Vogel NE, Hoek A, et al. Minimal stimulation IVF with late follicular phase administration of the GnRH antagonist cetrorelix and concomitant substitution with recombinant FSH: a pilot study. Hum Reprod. 2005;20(3):642-8. Full Text: Exclude Q3-Not RCT. [pmid: 15608031].
Penzias AS, Alper MM. Luteal support with vaginal micronized progesterone gel in assisted reproduction. Reproductive Biomedicine Online. 2003;6(3):287-95. Full Text: Exclude Q3-Not original research. [pmid: 12735861].
Perez-Medina T, Bajo-Arenas J, Salazar F, et al. Endometrial polyps and their implication in the pregnancy rates of patients undergoing intrauterine insemination: a prospective, randomized study. Hum Reprod. 2005;20(6):1632-5. Full Text: Exclude Q3-Donor egg; Full Text: Include Q2. [pmid: 15760959].
Perni SC, Predanic M, Cho JE, et al. Placental pathology and pregnancy outcomes in donor and non-donor oocyte in vitro fertilization pregnancies.[erratum appears in J Perinat Med. 2005;33(2):186 Note: Predanik, Mladen [corrected to Predanic, Mladen]]. J Perinat Med. 2005;33(1):27-32. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 15841610].
Petignat P, Vassilakos P, Campana A. Are fertility drugs a risk factor for persistent trophoblastic tumour?. Hum Reprod. 2002;17(6):1610-5. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 12042286].
Phelps JY, Hickman TN, Robinson RD, et al. A military health care facility has high in vitro fertilization success rates. Mil Med. 2000;165(12):935-7. Full Text: Exclude Q3-Not RCT. [pmid: 11149065].
Phillips SJ, Dean NL, Buckett WM, et al. Consecutive transfer of day 3 embryos and of day 5–6 blastocysts increases overall pregnancy rates associated with blastocyst culture. J Assist Reprod Genet. 2003;20(11):461-4. Full Text: Exclude Q3-Not RCT. [pmid: 14714825].
Pinborg A, Loft A, Nyboe Andersen A. Neonatal outcome in a Danish national cohort of 8602 children born after in vitro fertilization or intracytoplasmic sperm injection: the role of twin pregnancy. Acta Obstet Gynecol Scand. 2004;83(11):1071-8. Full Text: Exclude Q4-Outcome comparing twin to singleton. [pmid: 15488125].
Pirard C, Donnez J, Loumaye E. GnRH agonist as luteal phase support in assisted reproduction technique cycles: results of a pilot study. Hum Reprod. 2006;21(7):1894-900. Full Text: Exclude Q3-Unable to calculate pregnancy rate. [pmid: 16556673].
Platt MJ, Marshall A, Pharoah PO. The effects of assisted reproduction on the trends and zygosity of multiple births in England and Wales 1974-99. Twin Research. 2001;4(6):417-21. Full Text: Exclude Q4-Demographic trends only; no estimation of risk based on known exposures. [pmid: 11780931].
Pope CS, Cook EK, Arny M, et al. Influence of embryo transfer depth on in vitro fertilization and embryo transfer outcomes. Fertil Steril. 2004;81(1):51-8. Full Text: Exclude Q3-Not RCT. [pmid: 14711544].
Popovic-Todorovic B, Loft A, Ziebe S, et al. Impact of recombinant FSH dose adjustments on ovarian response in the second treatment cycle with IVF or ICSI in “standard” patients treated with 150 IU/day during the first cycle. Acta Obstet Gynecol Scand. 2004;83(9):842-9. Full Text: Exclude Q3-Not RCT. [pmid: 15315596].
Poustie VJ, Dodd S, Drakeley AJ. Low-dose aspirin for in vitro fertilisation [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 4. Art. No.: CD004832. DOI:10.1002/14651858.CD004832.pub2. Full Text: Exclude Q3-Review article (Cochrane).
Prapas N, Prapas Y, Panagiotidis Y, et al. Cervical dilatation has a positive impact on the outcome of IVF in randomly assigned cases having two previous difficult embryo transfers. Hum Reprod. 2004;19(8):1791-5. Full Text: Exclude-Not relevant to any question. [pmid: 15178658].
Prapas N, Prapas Y, Panagiotidis Y, et al. GnRH agonist versus GnRH antagonist in oocyte donation cycles: a prospective randomized study. Hum Reprod. 2005;20(6):1516-20. Full Text: Exclude Q3-Donor egg. [pmid: 15860501].
Prapas Y, Prapas N, Hatziparasidou A, et al. Ultrasound-guided embryo transfer maximizes the IVF results on day 3 and day 4 embryo transfer but has no impact on day 5. Hum Reprod. 2001;16(9):1904-8. Full Text: Exclude Q3-Not RCT. [pmid: 11527896].
Pritts EA. Treatment of the infertile patient with polycystic ovarian syndrome. Obstet Gynecol Surv. 2002;57(9):587-97. Full Text: Exclude Q2-Background article. [pmid: 12218667].
Pruksananonda C. Growth and development of children conceived by intracytoplasmic sperm injection at King Chulalongkorn Memorial Hospital. J Med Assoc Thai. 2001;84(Suppl 1):S76-85. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 11529384].
Racowsky C, Jackson KV, Cekleniak NA, et al. The number of eight-cell embryos is a key determinant for selecting day 3 or day 5 transfer. Fertil Steril. 2000;73(3):558-64. Full Text: Exclude Q3-Not RCT. [pmid: 10689013].
Racowsky C, Orasanu B, Hinrichsen MJ, et al. Embryo quality based on ovulation induction: defining the differences. Reproductive Biomedicine Online. 2005;11(1):22-5. Full Text: Exclude Q2-Not RCT. [pmid: 16102282].
Ragni G, Mosconi P, Baldini MP, et al. Health-related quality of life and need for IVF in 1000 Italian infertile couples. Hum Reprod. 2005;20(5):1286-91. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 15695309].
Raimondi S, Pedotti P, Taioli E. APIKIDS: a cohort of children born after assisted reproductive technologies. Paediatr Perinat Epidemiol. 2006;20(5):411-5. Full Text: Exclude Q4-No outcomes data. [pmid: 16911020].
Raman JD, Schlegel PN. Testicular sperm extraction with intracytoplasmic sperm injection is successful for the treatment of nonobstructive azoospermia associated with cryptorchidism. J Urol. 2003;170(4 Pt 1):1287-90. Full Text: Exclude Q3-Not RCT. [pmid: 14501743].
Ramsewak SS, Duffy S, Taylor J, et al. The oral contraceptive pill effectively permits cycle batching for an intermittent in vitro fertilization programme in Trinidad and Tobago. West Indian Med J. 2005;54(2):127-9. Full Text: Exclude Q3-Not RCT. [pmid: 15999883].
Raty R, Virtanen A, Koskinen P, et al. Serum free beta-HCG and alpha-fetoprotein levels in IVF, ICSI and frozen embryo transfer pregnancies in maternal mid-trimester serum screening for Down's syndrome. Hum Reprod. 2002;17(2):481-4. Full Text: Exclude Q4-No pregnancy outcome. [pmid: 11821299].
Ravhon A, Aurell R, Lawrie H, et al. The significance of delayed suppression using buserelin acetate and recombinant follicle-stimulating hormone in a long protocol in vitro fertilization program. Fertil Steril. 2000;73(2):325-9. Full Text: Exclude Q3-Not RCT. [pmid: 10685537].
Reddy UM, Wapner RJ, Rebar RW, et al. Infertility, assisted reproductive technology, and adverse pregnancy outcomes: executive summary of a National Institute of Child Health and Human Development workshop. Obstet Gynecol. 2007;109(4):967-77. Full Text: Exclude Q4-Background article. [pmid: 17400861].
Redshaw M, Hockley C, Davidson LL. A qualitative study of the experience of treatment for infertility among women who successfully became pregnant. Hum Reprod. 2007;22(1):295-304. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 16959809].
Ren SS, Sun GH, Ku CH, et al. Comparison of four methods for sperm preparation for IUI. Arch Androl. 2004;50(3):139-43. Full Text: Exclude Q2-Not RCT. [pmid: 15204678].
Reynolds MA, Schieve LA, Jeng G, et al. Does insurance coverage decrease the risk for multiple births associated with assisted reproductive technology?. Fertil Steril. 2003;80(1):16-23. Full Text: Exclude Q3-Not RCT. [pmid: 12849794].
Rhouma KB, Miled EB, Attallah K, et al. Successful pregnancies after using immotile spermatozoa from ejaculate, epididymis and testis. Eur J Obstet Gynecol Reprod Biol. 2003;108(2):182-5. Full Text: Exclude Q3-Not RCT. [pmid: 12781408].
Richmond JR, Deshpande N, Lyall H, et al. Follicular diameters in conception cycles with and without multiple pregnancy after stimulated ovulation induction. Hum Reprod. 2005;20(3):756-60. Full Text: Exclude Q2-Not RCT. [pmid: 15608033].
Richter KS, Anderson M, Osborn BH. Selection for faster development does not bias sex ratios resulting from blastocyst embryo transfer. Reproductive Biomedicine Online. 2006;12(4):460-5. Full Text: Exclude Q4-No controls. [pmid: 16740219].
Rienzi L, Ubaldi F, Iacobelli M, et al. Day 3 embryo transfer with combined evaluation at the pronuclear and cleavage stages compares favourably with day 5 blastocyst transfer. Hum Reprod. 2002;17(7):1852-5. Full Text: Exclude Q3-Data not per patient. [pmid: 12093851].
Ries LAG, Melbert D, Krapcho M, et al. SEER Cancer Statistics Review, 1975-2004, National Cancer Institute. Bethesda, MD, http://seer.cancer.gov/csr/1975_2004/, based on November 2006 SEER data submission, posted to the SEER web site, 2007. Full Text: Exclude Q4-Background article
Rimm AA, Katayama AC, Diaz M, et al. A meta-analysis of controlled studies comparing major malformation rates in IVF and ICSI infants with naturally conceived children. J Assist Reprod Genet. 2004;21(12):437-43. Full Text: Exclude Q4-Review article. [pmid: 15704519].
Robb PA, Robins JC, Thomas MA. Timing of hCG administration does not affect pregnancy rates in couples undergoing intrauterine insemination using clomiphene citrate. J Natl Med Assoc. 2004;96(11):1431-3. Full Text: Exclude Q3-Not RCT. [pmid: 15586646]. [pmcid: 2568619].
Roman E, Aytoz A, Smitz JE, et al. Analysis of the bleeding pattern in assisted reproduction cycles with luteal phase supplementation using vaginal micronized progesterone. Hum Reprod. 2000;15(7):1435-9. Full Text: Exclude Q3-Not RCT. [pmid: 10875847].
Rossi-Ferragut LM, Iaconelli A Jr, Aoki T, et al. Pronuclear and morphological features as a cumulative score to select embryos in ICSI (intracytoplasmic sperm injection) cycles according to sperm origin. J Assist Reprod Genet. 2003;20(1):1-7. Full Text: Exclude Q3-Not RCT. [pmid: 12656060].
Rossignol S, Steunou V, Chalas C, et al. The epigenetic imprinting defect of patients with Beckwith-Wiedemann syndrome born after assisted reproductive technology is not restricted to the 11p15 region. J Med Genet. 2006;43(12):902-7. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 16825435].
Ryan GL, Zhang SH, Dokras A, et al. The desire of infertile patients for multiple births. Fertil Steril. 2004;81(3):500-4. Full Text: Exclude Q4-No controls. [pmid: 15037390].
Sachs AR, Politch JA, Jackson KV, et al. Factors associated with the formation of triploid zygotes after intracytoplasmic sperm injection. Fertil Steril. 2000;73(6):1109-14. Full Text: Exclude Q3-Not RCT. [pmid: 10856466].
Saldeen P, Sundstrom P. Would legislation imposing single embryo transfer be a feasible way to reduce the rate of multiple pregnancies after IVF treatment?. Hum Reprod. 2005;20(1):4-8. Full Text: Exclude Q3-Not RCT. [pmid: 15567878].
Salihu HM, Aliyu MH, Rouse DJ, et al. Potentially preventable excess mortality among higher-order multiples. Obstet Gynecol. 2003;102(4):679-84. Full Text: Exclude Q4-Outcomes not correlated with history or infertility or treatment. [pmid: 14550995].
Sallam HN, Agameya AF, Rahman AF, et al. Ultrasound measurement of the uterocervical angle before embryo transfer: a prospective controlled study. Hum Reprod. 2002;17(7):1767-72. Full Text: Exclude Q3-Not RCT. [pmid: 12093837].
Sallam HN, Farrag A, Agameya AF, et al. The use of the modified hypo-osmotic swelling test for the selection of immotile testicular spermatozoa in patients treated with ICSI: a randomized controlled study. Hum Reprod. 2005;20(12):3435-40. Full Text: Exclude Q3-Not RCT. [pmid: 16126756].
Sallam HN, Garcia-Velasco JA, Dias S, et al. Long-term pituitary down-regulation before in vitro fertilization (IVF) for women with endometriosis [Full Review]. Cochrane Database of Systematic Reviews 2006, Issue 1. Art. No.: CD004635. DOI: 10.1002/14651858.CD004635.pub2. Full Text: Exclude Q3-Review article (Cochrane).
Sallam HN, Sadek SS. Ultrasound-guided embryo transfer: a meta-analysis of randomized controlled trials. Fertil Steril. 2003;80(4):1042-6. Full Text: Exclude Q3-Review article. [pmid: 14556831].
Sallam HN, Sadek SS, Agameya AF. Assisted hatching—a meta-analysis of randomized controlled trials. J Assist Reprod Genet. 2003;20(8):332-42. Full Text: Exclude Q3-Review article. [pmid: 12948097].
Salumets A, Hyden-Granskog C, Makinen S, et al. Early cleavage predicts the viability of human embryos in elective single embryo transfer procedures. Hum Reprod. 2003;18(4):821-5. Full Text: Exclude Q3-Not RCT. [pmid: 12660278].
Salumets A, Suikkari AM, Makinen S, et al. Frozen embryo transfers: implications of clinical and embryological factors on the pregnancy outcome. Hum Reprod. 2006;21(9):2368-74. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 16684837].
Salumets A, Tuuri T, Makinen S, et al. Effect of developmental stage of embryo at freezing on pregnancy outcome of frozen-thawed embryo transfer. Hum Reprod. 2003;18(9):1890-5. Full Text: Exclude Q3-Not RCT. [pmid: 12923145].
Sanchez-Albisua I, Borell-Kost S, Mau-Holzmann UA, et al. Increased frequency of severe major anomalies in children conceived by intracytoplasmic sperm injection. Developmental Medicine & Child Neurology. 2007;49(2):129-34. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 17254001].
Sayyah Melli M, Gasemzadeh A, Alizadeh M. Spontaneous pregnancy after clomiphene citrate failure. Int J Gynaecol Obstet. 2005;91(2):179-81. Full Text: Exclude Q3-Not RCT. [pmid: 16126209].
Schieve LA, Ferre C, Peterson HB, et al. Perinatal outcome among singleton infants conceived through assisted reproductive technology in the United States. Obstet Gynecol. 2004;103(6):1144-53. Full Text: Exclude Q4-No 2×2 table. [pmid: 15172846].
Schieve LA, Meikle SF, Peterson HB, et al. Does assisted hatching pose a risk for monozygotic twinning in pregnancies conceived through in vitro fertilization?. Fertil Steril. 2000;74(2):288-94. Full Text: Exclude Q3-Not RCT. [pmid: 10927046].
Schieve LA, Rasmussen SA, Buck GM, et al. Are children born after assisted reproductive technology at increased risk for adverse health outcomes?. Obstet Gynecol. 2004;103(6):1154-63. Full Text: Exclude Q4-Background article. [pmid: 15172847].
Schmidt DW, Engmann LL, Siano LJ, et al. Influence of embryo quality and number of previous cycles on pregnancy and multiple pregnancy rates in women aged 35 to 37 years who received two or three embryos. Fertil Steril. 2005;84(6):1748-51. Full Text: Exclude Q3-Not RCT. [pmid: 16359982].
Schmidt DW, Maier DB, Nulsen JC, et al. Reducing the dose of human chorionic gonadotropin in high responders does not affect the outcomes of in vitro fertilization. Fertil Steril. 2004;82(4):841-6. Full Text: Exclude Q3-Not RCT. [pmid: 15482757].
Schmidt KL, Ziebe S, Popovic B, et al. Progesterone supplementation during early gestation after in vitro fertilization has no effect on the delivery rate. Fertil Steril. 2001;75(2):337-41. Full Text: Exclude Q3-Not RCT. [pmid: 11172836].
Schmidt L, Holstein BE, Christensen U, et al. Communication and coping as predictors of fertility problem stress: cohort study of 816 participants who did not achieve a delivery after 12 months of fertility treatment. Hum Reprod. 2005;20(11):3248-56. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 16006458].
Schnorr JA, Doviak MJ, Muasher SJ, et al. Impact of a cryopreservation program on the multiple pregnancy rate associated with assisted reproductive technologies. Fertil Steril. 2001;75(1):147-51. Full Text: Exclude Q3-Not RCT. [pmid: 11163830].
Schoolcraft WB, Gardner DK. Blastocyst culture and transfer increases the efficiency of oocyte donation. Fertil Steril. 2000;74(3):482-6. Full Text: Exclude Q3-Not RCT. [pmid: 10973642].
Schoolcraft WB, Surrey ES, Minjarez DA, et al. Management of poor responders: can outcomes be improved with a novel gonadotropin-releasing hormone antagonist/letrozole protocol?. Fertil Steril. 2008;89(1):151-6. Full Text: Exclude Q3-Not RCT. [pmid: 17482177].
Schwarzler P, Abendstein BJ, Klingler A, et al. Prevention of severe ovarian hyperstimulation syndrome (OHSS) in IVF patients by steroidal ovarian suppression—a prospective randomized study. Human Fertility. 2003;6(3):125-9. Full Text: Exclude Q3-Data not per patient. [pmid: 12960445].
Schwarzler P, Zech H, Auer M, et al. Pregnancy outcome after blastocyst transfer as compared to early cleavage stage embryo transfer. Hum Reprod. 2004;19(9):2097-102. Full Text: Exclude Q3-Not RCT. [pmid: 15243002].
Scotland GS, McNamee P, Peddie VL, et al. Safety versus success in elective single embryo transfer: women's preferences for outcomes of in vitro fertilisation. BJOG. 2007;114(8):977-83. Full Text: Exclude Q4-Background article. [pmid: 17578474].
Sedbon E, Wainer R, Perves C. Quality of life of patients undergoing ovarian stimulation with injectable drugs in relation to medical practice in France. Reproductive Biomedicine Online. 2006;12(3):298-303. Full Text: Exclude-Not relevant to any question. [pmid: 16569316].
Seeber BE, Barnhart KT. Suspected ectopic pregnancy [erratum appears in Obstet Gynecol. 2006 Apr;107(4):955]. Obstet Gynecol. 2006;107(2 Pt 1):399-413. Full Text: Exclude Q4-Background article. [pmid: 16449130].
Seelig AS, Al-Hasani S, Katalinic A, et al. Comparison of cryopreservation outcome with gonadotropin-releasing hormone agonists or antagonists in the collecting cycle. Fertil Steril. 2002;77(3):472-5. Full Text: Exclude Q3-Not RCT. [pmid: 11872197].
Seif MMW, Edi-Osagie ECO, Farquhar C, et al. Assisted hatching on assisted conception (IVF & ICSI) [Full Review]. Cochrane Database of Systematic Reviews 2006, Issue 1. Art. No.: CD001894. DOI: 10.1002/14651858.CD001894.pub3. Full Text: Exclude Q3-Review article (Cochrane).
Senn A, Vozzi C, Chanson A, et al. Prospective randomized study of two cryopreservation policies avoiding embryo selection: the pronucleate stage leads to a higher cumulative delivery rate than the early cleavage stage. Fertil Steril. 2000;74(5):946-52. Full Text: Exclude Q3-Not RCT. [pmid: 11056238].
Serhal P, Ranieri DM, Khadum I, et al. Cervical dilatation with hygroscopic rods prior to ovarian stimulation facilitates embryo transfer. Hum Reprod. 2003;18(12):2618-20. Full Text: Exclude Q3-Not RCT. [pmid: 14645181].
Seta M. Embryo transfer after autologous endometrial coculture improves pregnancy rates. Hum Cell. 2001;14(2):135-40. Full Text: Exclude Q3-Not RCT. [pmid: 11552293].
Setti PE, Cavagna M, Albani E, et al. Outcome of assisted reproductive technologies after different embryo transfer strategies. Reproductive Biomedicine Online. 2005;11(1):64-70. Full Text: Exclude Q3-Not RCT. [pmid: 16102290].
Shamonki MI, Spandorfer SD, Rosenwaks Z. Ultrasound-guided embryo transfer and the accuracy of trial embryo transfer. Hum Reprod. 2005;20(3):709-16. Full Text: Exclude Q3-Not RCT. [pmid: 15689350].
Shanbhag S, Aucott L, Bhattacharya S, et al. Interventions for ‘poor responders’ to controlled ovarian hyperstimulation (COH) in in-vitro fertilisation (IVF) [Full Review]. Cochrane Database of Systematic Reviews 2007, Issue 1. Art. No.: CD004379. DOI: 10.1002/14651858.CD004379.pub2. Full Text: Exclude Q3-Review article (Cochrane).
Shapiro BS, Richter KS, Harris DC, et al. A comparison of day 5 and day 6 blastocyst transfers. Fertil Steril. 2001;75(6):1126-30. Full Text: Exclude Q3-Not RCT. [pmid: 11384637].
Shapiro DB, Mitchell-Leef D, Carter M, et al. Ganirelix acetate use in normal- and poor-prognosis patients and the impact of estradiol patterns. Fertil Steril. 2005;83(3):666-70. Full Text: Exclude Q3-Not RCT. [pmid: 15749496].
Sharara FI, McClamrock HD. Use of microdose GnRH agonist protocol in women with low ovarian volumes undergoing IVF. Hum Reprod. 2001;16(3):500-3. Full Text: Exclude Q3-Not RCT. [pmid: 11228219].
Shen S, Khabani A, Klein N, et al. Statistical analysis of factors affecting fertilization rates and clinical outcome associated with intracytoplasmic sperm injection. Fertil Steril. 2003;79(2):355-60. Full Text: Exclude Q3-Not RCT. [pmid: 12568845].
Sher G, Fisch JD. Effect of vaginal sildenafil on the outcome of in vitro fertilization (IVF) after multiple IVF failures attributed to poor endometrial development. Fertil Steril. 2002;78(5):1073-6. Full Text: Exclude Q3-Not RCT. [pmid: 12413996].
Sher G, Keskintepe L, Batzofin J, et al. Influence of early ICSI-derived embryo sHLA-G expression on pregnancy and implantation rates: a prospective study. Hum Reprod. 2005;20(5):1359-63. Full Text: Exclude Q3-Not RCT. [pmid: 15746200].
Shulman A, Maymon R. Mid-gestation Down syndrome screening test and pregnancy outcome among unstimulated assisted-conception pregnancies. Prenat Diagn. 2003;23(8):625-8. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 12913867].
Siegelmann-Danieli N, Tamir A, Zohar H, et al. Breast cancer in women with recent exposure to fertility medications is associated with poor prognostic features. Ann Surg Oncol. 2003;10(9):1031-8. Full Text: Exclude Q2-Not RCT; Full Text: Exclude Q4-Not true case-control or cohort. [pmid: 14597441].
Silberstein T, Weitzen S, Frankfurter D, et al. Cannulation of a resistant internal os with the malleable outer sheath of a coaxial soft embryo transfer catheter does not affect in vitro fertilization-embryo transfer outcome. Fertil Steril. 2004;82(5):1402-6. Full Text: Exclude Q3-Not RCT. [pmid: 15533367].
Sills ES, Drews CD, Perloe M, et al. Periovulatory serum human chorionic gonadotropin (hCG) concentrations following subcutaneous and intramuscular nonrecombinant hCG use during ovulation induction: a prospective, randomized trial. Fertil Steril. 2001;76(2):397-9. Full Text: Exclude Q2-No pregnancy outcome. [pmid: 11476796].
Silverman AY, Stephens SR, Drouin MT, et al. Female sex selection using clomiphene citrate and albumin separation of human sperm. Hum Reprod. 2002;17(5):1254-6. Full Text: Exclude Q3-Not RCT. [pmid: 11980748].
Sinawat S, Buppasiri P, Lumbiganon P, et al. Long versus short course treatment with Metformin and Clomiphene Citrate for ovulation induction in women with PCOS [Full Review]. Cochrane Database of Systematic Reviews 2008, Issue 1. Art. No.: CD006226. DOI: 10.1002/14651858.CD006226.pub2. Full Text: Exclude Q2-Review article (Cochrane).
Sipe CS, Davis WA, Maifeld M, et al. A prospective randomized trial comparing anastrozole and clomiphene citrate in an ovulation induction protocol using gonadotropins. Fertil Steril. 2006;86(6):1676-81. Full Text: Exclude Q2-Crossover data not available for 1st cycle. [pmid: 17007849].
Sjoblom P, Menezes J, Cummins L, et al. Prediction of embryo developmental potential and pregnancy based on early stage morphological characteristics. Fertil Steril. 2006;86(4):848-61. Full Text: Exclude Q2-Not RCT. [pmid: 17027355].
Smith KL, Grow DR, Wiczyk HP, et al. Does catheter type effect pregnancy rate in intrauterine insemination cycles?. J Assist Reprod Genet. 2002;19(2):49-52. Full Text: Exclude Q2-Not RCT; Full Text: Exclude Q3-Not RCT. [pmid: 11958504].
Soares SR, Simon C, Remohi J, et al. Cigarette smoking affects uterine receptiveness. Hum Reprod. 2007;22(2):543-7. Full Text: Exclude-Not relevant to any question. [pmid: 17095517].
Soderstrom-Anttila V, Makinen S, Tuuri T, et al. Favourable pregnancy results with insemination of in vitro matured oocytes from unstimulated patients. Hum Reprod. 2005;20(6):1534-40. Full Text: Exclude Q3-Not RCT. [pmid: 15695312].
Soderstrom-Anttila V, Salokorpi T, Pihlaja M, et al. Obstetric and perinatal outcome and preliminary results of development of children born after in vitro maturation of oocytes. Hum Reprod. 2006;21(6):1508-13. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 16449308].
Somigliana E, Infantino M, Benedetti F, et al. The presence of ovarian endometriomas is associated with a reduced responsiveness to gonadotropins. Fertil Steril. 2006;86(1):192-6. Full Text: Exclude-Not relevant to any question. [pmid: 16716316].
Sousa M, Cremades N, Silva J, et al. Predictive value of testicular histology in secretory azoospermic subgroups and clinical outcome after microinjection of fresh and frozen-thawed sperm and spermatids. Hum Reprod. 2002;17(7):1800-10. Full Text: Exclude Q3-Not RCT. [pmid: 12093843].
Spandorfer S, Navarro J, Kump LM, et al. “Co-Flare” stimulation in the poor responder patient: predictive value of the flare response. J Assist Reprod Genet. 2001;18(12):629-33. Full Text: Exclude Q3-Not RCT. [pmid: 11808842].
Spandorfer SD, Barmat LI, Navarro J, et al. Importance of the biopsy date in autologous endometrial cocultures for patients with multiple implantation failures. Fertil Steril. 2002;77(6):1209-13. Full Text: Exclude Q3-Not RCT. [pmid: 12057730].
Spandorfer SD, Pascal P, Parks J, et al. Autologous endometrial coculture in patients with IVF failure: outcome of the first 1,030 cases. J Reprod Med. 2004;49(6):463-7. Full Text: Exclude Q3-Not RCT. [pmid: 15283055].
Spandorfer SD, Soslow R, Clark R, et al. Histologic characteristics of the endometrium predicts success when utilizing autologous endometrial coculture in patients with IVF failure. J Assist Reprod Genet. 2006;23(4):185-9. Full Text: Exclude-Not relevant to any question. [pmid: 16758349].
Stadtmauer LA, Riehl RM, Toma SK, et al. Cauterization of hydrosalpinges before in vitro fertilization is an effective surgical treatment associated with improved pregnancy rates. Am J Obstet Gynecol. 2000;183(2):367-71. Full Text: Exclude Q3-Not RCT. [pmid: 10942471].
Stadtmauer LA, Toma SK, Riehl RM, et al. Impact of metformin therapy on ovarian stimulation and outcome in ‘coasted’ patients with polycystic ovary syndrome undergoing in-vitro fertilization. Reproductive Biomedicine Online. 2002;5(2):112-6. Full Text: Exclude Q3-Not RCT. [pmid: 12419034].
Steiner AZ, Paulson RJ, Hartmann KE. Effects of competition among fertility centers on pregnancy and high-order multiple gestation rates. Fertil Steril. 2005;83(5):1429-34. Full Text: Exclude Q3-Not RCT. [pmid: 15866580].
Steiner AZ, Terplan M, Paulson RJ. Comparison of tamoxifen and clomiphene citrate for ovulation induction: a meta-analysis. Hum Reprod. 2005;20(6):1511-5. Full Text: Exclude Q2-Review article. [pmid: 15845599].
Steinman G. Mechanisms of twinning. VI. Genetics and the etiology of monozygotic twinning in in vitro fertilization. J Reprod Med. 2003;48(8):583-90. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 12971137].
Steures P, van der Steeg JW, Verhoeve HR, et al. Does ovarian hyperstimulation in intrauterine insemination for cervical factor subfertility improve pregnancy rates?. Hum Reprod. 2004;19(10):2263-6. Full Text: Exclude Q3-Not RCT. [pmid: 15333600].
Stewart JE, Allred EN, Collins M, et al. Risk of cranial ultrasound abnormalities in very-low-birth-weight infants conceived with assisted reproductive techniques. J Perinatol. 2002;22(1):37-45. Full Text: Exclude Q4-Unable to analyze data. [pmid: 11840241].
Stone BA, Greene J, Vargyas JM, et al. Embryo fragmentation as a determinant of blastocyst development in vitro and pregnancy outcomes following embryo transfer. Am J Obstet Gynecol. 2005;192(6):2014-9. discussion 2019–20. Full Text: Exclude Q3-Not RCT. [pmid: 15970880].
Strandell A, Lindhard A, Eckerlund I. Cost—effectiveness analysis of salpingectomy prior to IVF, based on a randomized controlled trial. Hum Reprod. 2005;20(12):3284-92. Full Text: Exclude Q3-No pregnancy outcome. [pmid: 16096324].
Strawn EY Jr, Roesler M, Rinke M, et al. Minimal precycle testing and ongoing cycle monitoring for in vitro fertilization and fresh pre-embryo transfer do not compromise fertilization, implantation, or ongoing pregnancy rates. Am J Obstet Gynecol. 2000;182(6):1623-8. Full Text: Exclude-Not relevant to any question. [pmid: 10871488].
Sturrock ND, Lannon B, Fay TN. Metformin does not enhance ovulation induction in clomiphene resistant polycystic ovary syndrome in clinical practice. Br J Clin Pharmacol. 2002;53(5):469-73. Full Text: Exclude Q2-Crossover data not available for 1st cycle. [pmid: 11994052]. [pmcid: 1874363].
Summers-Chase D, Check JH, Swenson K, et al. A comparison of in vitro fertilization outcome by culture media used for developing cleavage-stage embryos. Clin Exp Obstet Gynecol. 2004;31(3):179-82. Full Text: Exclude Q3-Not RCT. [pmid: 15495357].
Sunderam S, Schieve LA, Cohen B, et al. Linking birth and infant death records with assisted reproductive technology data: Massachusetts, 1997-1998. Maternal & Child Health Journal. 2006;10(2):115-25. Full Text: Exclude Q4-No outcomes data. [pmid: 16328709].
Sutcliffe AG, Peters CJ, Bowdin S, et al. Assisted reproductive therapies and imprinting disorders—a preliminary British survey. Hum Reprod. 2006;21(4):1009-11. Full Text: Exclude Q4-Not true case-control or cohort. [pmid: 16361294].
Suzuki Y, Sugiyama R, Fukumine N, et al. Clinical applications of serum placental protein 14 (PP14) measurement in the IVF-ET cycle. J Obstet Gynaecol Res. 2000;26(4):295-302. Full Text: Exclude Q3-Not RCT. [pmid: 11049241].
Swenson K, Check JH, Summers-Chase D, et al. A randomized study comparing the effect of standard versus short incubation of sperm and oocyte on subsequent pregnancy and implantation rates following in vitro fertilization embryo transfer. Arch Androl. 2000;45(1):73-6. Full Text: Exclude Q3-Not RCT. [pmid: 10959505].
Szilagyi A, Bartfai G, Manfai A, et al. Low-dose ovulation induction with urinary gonadotropins or recombinant follicle stimulating hormone in patients with polycystic ovary syndrome. Gynecol Endocrinol. 2004;18(1):17-22. Full Text: Exclude Q2-No N per group. [pmid: 15106360].
Szymankiewicz M, Jedrzejczak P, Rozycka J, et al. Newborn outcome after assisted reproductive technology: experiences and reflections from Poland. International Journal of Fertility & Womens Medicine. 2004;49(4):150-4. Full Text: Exclude Q4-Not true case-control or cohort.
Tabs D, Vejnovic T, Radunovic N. Preterm and premature rupture of membranes in pregnancies after in vitro fertilization. Med Pregl. 2005;58(78):375-9. Full Text: Exclude-Not relevant to any question. [pmid: 16296581].
Takeuchi S, Futamura N, Takubo S, et al. Polycystic ovary syndrome treated with laparoscopic ovarian drilling with a harmonic scalpel. A prospective, randomized study. J Reprod Med. 2002;47(10):816-20. Full Text: Exclude-Not relevant to any question. [pmid: 12418063].
Takeuchi S, Minoura H, Shibahara T, et al. Comparison of piezo-assisted micromanipulation with conventional micromanipulation for intracytoplasmic sperm injection into human oocytes. Gynecol Obstet Invest. 2001;52(3):158-62. Full Text: Exclude Q3-Not RCT. [pmid: 11598356].
Takeuchi S, Minoura H, Shibahara T, et al. A prospective randomized comparison of routine buserelin acetate and a decreasing dosage of nafarelin acetate with a low-dose gonadotropin-releasing hormone agonist protocol for in vitro fertilization and intracytoplasmic sperm injection. Fertil Steril. 2001;76(3):532-7. Full Text: Exclude Q2-Not RCT; Full Text: Exclude Q3-Not RCT. [pmid: 11532477].
Tanahatoe SJ, Lambalk CB, Hompes PG. The role of laparoscopy in intrauterine insemination: a prospective randomized reallocation study. Hum Reprod. 2005;20(11):3225-30. Full Text: Exclude Q2-No pregnancy outcome. [pmid: 16006455].
Tarlatzis BC, Bili H. Intracytoplasmic sperm injection. Survey of world results. Ann N Y Acad Sci. 2000;900:336-44. Full Text: Exclude Q3-Not RCT. [pmid: 10818422].
Tasdemir S, Ficicioglu C, Yalti S, et al. The effect of metformin treatment to ovarian response in cases with PCOS. Arch Gynecol Obstet. 2004;269(2):121-4. Full Text: Exclude Q2-Method of randomization NR. [pmid: 12764624].
Tavmergen E, Goker EN, Sendag F, et al. Comparison of short and long ovulation induction protocols used in ART applications according to the ovarian response and outcome of pregnancy. Arch Gynecol Obstet. 2002;266(1):5-11. Full Text: Exclude Q3-Not RCT. [pmid: 11998967].
Tepla O, Peknicova J, Koci K, et al. Evaluation of reproductive potential after intracytoplasmic sperm injection of varied human semen tested by antiacrosomal antibodies. Fertil Steril. 2006;86(1):113-20. Full Text: Exclude Q3-Not RCT. [pmid: 16750209].
Terriou P, Hans E, Giorgetti C, et al. Pentoxifylline initiates motility in spontaneously immotile epididymal and testicular spermatozoa and allows normal fertilization, pregnancy, and birth after intracytoplasmic sperm injection. J Assist Reprod Genet. 2000;17(4):194-9. Full Text: Exclude Q3-Not RCT. [pmid: 10955242].
Tesarik J, Hazout A, Mendoza C. Enhancement of embryo developmental potential by a single administration of GnRH agonist at the time of implantation. Hum Reprod. 2004;19(5):1176-80. Full Text: Exclude Q3-Donor egg. [pmid: 15070873].
Thapar A, Harold G, Rice F, et al. Do intrauterine or genetic influences explain the foetal origins of chronic disease? A novel experimental method for disentangling effects. BMC Medical Research Methodology. 2007;7:25. Full Text: Exclude Q4-Donor egg. [pmid: 17587444]. [pmcid: 1913535].
Thatcher SS, Jackson EM. Pregnancy outcome in infertile patients with polycystic ovary syndrome who were treated with metformin. Fertil Steril. 2006;85(4):1002-9. Full Text: Exclude Q4-No controls. [pmid: 16580387].
Thornton JG. Progesterone and preterm labor—still no definite answers. N Engl J Med. 2007;357(5):499-501. Full Text: Exclude Q4-Background article. [pmid: 17671259].
Thurin A, Hardarson T, Hausken J, et al. Predictors of ongoing implantation in IVF in a good prognosis group of patients. Hum Reprod. 2005;20(7):1876-80. Full Text: Exclude Q3-Data not per patient. [pmid: 15774540].
Tiitinen A, Halttunen M, Harkki P, et al. Elective single embryo transfer: the value of cryopreservation. Hum Reprod. 2001;16(6):1140-4. Full Text: Exclude Q3-Not RCT. [pmid: 11387283].
Tiitinen A, Hyden-Granskog C, Gissler M. What is the most relevant standard of success in assisted reproduction?: The value of cryopreservation on cumulative pregnancy rates per single oocyte retrieval should not be forgotten. Hum Reprod. 2004;19(11):2439-41. Full Text: Exclude Q3-Not RCT. [pmid: 15319392].
Tiitinen A, Unkila-Kallio L, Halttunen M, et al. Impact of elective single embryo transfer on the twin pregnancy rate. Hum Reprod. 2003;18(7):1449-53. Full Text: Exclude Q3-Not RCT. [pmid: 12832371].
Toledo AA, Wright G, Jones AE, et al. Blastocyst transfer: a useful tool for reduction of high-order multiple gestations in a human assisted reproduction program. Am J Obstet Gynecol. 2000;183(2):377-9. dsicussion 380–2. Full Text: Exclude Q3-Not RCT. [pmid: 10942473].
Tough SC, Greene CA, Svenson LW, et al. Effects of in vitro fertilization on low birth weight, preterm delivery, and multiple birth. J Pediatr. 2000;136(5):618-22. Full Text: Exclude Q4-Population trends only. [pmid: 10802493].
Tournaye H, Verheyen G, Albano C, et al. Intracytoplasmic sperm injection versus in vitro fertilization: a randomized controlled trial and a meta-analysis of the literature. Fertil Steril. 2002;78(5):1030-7. Full Text: Exclude Q3-No pregnancy outcome. [pmid: 12413989].
Tozer AJ, Iles RK, Iammarrone E, et al. Characteristics of populations of granulosa cells from individual follicles in women undergoing ‘coasting’ during controlled ovarian stimulation (COS) for IVF. Hum Reprod. 2004;19(11):2561-8. Full Text: Exclude Q3-Not RCT. [pmid: 15471924].
Tremellen K, Miari G, Froiland D, et al. A randomised control trial examining the effect of an antioxidant (Menevit) on pregnancy outcome during IVF-ICSI treatment. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2007;47(3):216-21. Full Text: Exclude Q3-Male. [pmid: 17550489].
Trokoudes KM, Minbattiwalla MB, Kalogirou L, et al. Controlled natural cycle IVF with antagonist use and blastocyst transfer. Reproductive Biomedicine Online. 2005;11(6):685-9. Full Text: Exclude Q3-Not RCT. [pmid: 16417731].
Tsai MY, Huang FJ, Kung FT, et al. Influence of polyvinylpyrrolidone on the outcome of intracytoplasmic sperm injection. J Reprod Med. 2000;45(2):115-20. Full Text: Exclude Q3-Not RCT. [pmid: 10710741].
Tsai YL, Hwang JL, Loo TC, et al. Short-term postoperative GnRH analogue or danazol treatment after conservative surgery for stage III or IV endometriosis before ovarian stimulation: a prospective, randomized study. J Reprod Med. 2004;49(12):955-9. Full Text: Exclude Q3-No N per group. [pmid: 15656211].
Tung KH, Wilkens LR, Wu AH, et al. Effect of anovulation factors on pre- and postmenopausal ovarian cancer risk: revisiting the incessant ovulation hypothesis. Am J Epidemiol. 2005;161(4):321-9. Full Text: Exclude-Not relevant to any question. [pmid: 15692075].
Tur R, Barri PN, Coroleu B, et al. Use of a prediction model for high-order multiple implantation after ovarian stimulation with gonadotropins. Fertil Steril. 2005;83(1):116-21. Full Text: Exclude Q2-Not RCT. [pmid: 15652896].
Turner MJ, Walsh J, Byrne KM, et al. Outcome of clinical pregnancies after ovulation induction using metformin. Journal of Obstetrics & Gynaecology. 2006;26(3):233-5. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 16698631].
Twisk M, Mastenbroek S, van Wely M, et al. Preimplantation genetic screening for abnormal number of chromosomes (aneuploidies) in in vitro fertilisation or intracytoplasmic sperm injection [Full Review]. Cochrane Database of Systematic Reviews 2006, Issue 1. Art. No.: CD005291. DOI: 10.1002/14651858.CD005291.pub2. Full Text: Exclude Q3-Review article (Cochrane).
Twisk M, van der Veen F, Repping S, et al. Preferences of subfertile women regarding elective single embryo transfer: additional in vitro fertilization cycles are acceptable, lower pregnancy rates are not. Fertil Steril. 2007;88(4):1006-9. Full Text: Exclude Q4-Background article. [pmid: 17416363].
Ubaldi F, Rienzi L, Baroni E, et al. Cumulative pregnancy rates after transfer of fresh and thawed embryos. Eur J Obstet Gynecol Reprod Biol. 2004;115(Suppl1):S106-9. Full Text: Exclude Q3-Not RCT. [pmid: 15196727].
Ulug U, Bahceci M, Erden HF, et al. The significance of coasting duration during ovarian stimulation for conception in assisted fertilization cycles. Hum Reprod. 2002;17(2):310-3. Full Text: Exclude Q3-Not RCT. [pmid: 11821269].
Ulug U, Ben-Shlomo I, Bahceci M. Predictors of success during the coasting period in high-responder patients undergoing controlled ovarian stimulation for assisted conception. Fertil Steril. 2004;82(2):338-42. Full Text: Exclude Q2-Not RCT. [pmid: 15302281].
Ulug U, Bener F, Karagenc L, et al. Outcomes in couples undergoing ICSI: comparison between fresh and frozen-thawed surgically retrieved spermatozoa. Int J Androl. 2005;28(6):343-9. Full Text: Exclude Q3-Not RCT. [pmid: 16300666].
Ulug U, Tosun S, Jozwiak EA, et al. Subclinical pregnancy losses among women undergoing in-vitro fertilization with ICSI. J Assist Reprod Genet. 2006;23(6):261-7. Full Text: Exclude Q4-No outcomes of interest. [pmid: 16897436].
Urman B, Aksoy S, Alatas C, et al. Comparing two embryo transfer catheters. Use of a trial transfer to determine the catheter applied. J Reprod Med. 2000;45(2):135-8. Full Text: Exclude Q3-Not RCT. [pmid: 10710745].
Utsunomiya T, Ito H, Nagaki M, et al. A prospective, randomized study: day 3 versus hatching blastocyst stage.[erratum appears in Hum Reprod. 2005 Apr;20(4):1119]. Hum Reprod. 2004;19(7):1598-603. Full Text: Exclude Q3-Data not per patient. [pmid: 15142997].
Utsunomiya T, Naitou T, Nagaki M. A prospective trial of blastocyst culture and transfer. Hum Reprod. 2002;17(7):1846-51. Full Text: Exclude Q3-Not RCT. [pmid: 12093850].
Vahratian A, Schieve LA, Reynolds MA, et al. Live-birth rates and multiple-birth risk of assisted reproductive technology pregnancies conceived using thawed embryos, USA 1999-2000. Hum Reprod. 2003;18(7):1442-8. Full Text: Exclude Q3-Not RCT. [pmid: 12832370].
Vail A, Gardener E. Common statistical errors in the design and analysis of subfertility trials. Hum Reprod. 2003;18(5):1000-4. Full Text: Exclude Q2-Background article. [pmid: 12721176].
Valojerdi MR, Karimian L, Yazdi PE, et al. Efficacy of a human embryo transfer medium: a prospective, randomized clinical trial study. J Assist Reprod Genet. 2006;23(5):207-12. Full Text: Exclude Q3-Not RCT. [pmid: 16786421].
van de Pas MM, Weima S, Looman CW, et al. The use of fixed distance embryo transfer after IVF/ICSI equalizes the success rates among physicians. Hum Reprod. 2003;18(4):774-80. Full Text: Exclude Q3-Not RCT. [pmid: 12660270].
Van den Abbeel E, Camus M, Joris H, et al. Embryo freezing after intracytoplasmic sperm injection. Mol Cell Endocrinol. 2000;169(12):49-54. Full Text: Exclude Q3-Not RCT. [pmid: 11155954].
Van den Bergh MJ, Siragusa A, Dubied A, et al. The use of an hydrogen peroxide multipurpose isolator for inhouse preparation of human embryo culture media: a unique successful Swiss randomized prospective study. J Assist Reprod Genet. 2004;21(11):381-6. Full Text: Exclude Q3-Method of allocation to treatment unclear. [pmid: 15672950].
van der Gaast MH, Beier-Hellwig K, Fauser BC, et al. Endometrial secretion aspiration prior to embryo transfer does not reduce implantation rates. Reproductive Biomedicine Online. 2003;7(1):105-9. Full Text: Exclude Q3-Not RCT. [pmid: 12930588].
van der Westerlaken L, Naaktgeboren N, Verburg H, et al. Conventional in vitro fertilization versus intracytoplasmic sperm injection in patients with borderline semen: a randomized study using sibling oocytes. Fertil Steril. 2006;85(2):395-400. Full Text: Exclude Q3-Not RCT. [pmid: 16595217].
Van Horne AK, Bates GW Jr, Robinson RD, et al. Recombinant follicle-stimulating hormone (rFSH) supplemented with low-dose human chorionic gonadotropin compared with rFSH alone for ovarian stimulation for in vitro fertilization. Fertil Steril. 2007;88(4):1010-3. Full Text: Exclude Q3-Not RCT. [pmid: 17434503].
Van Langendonckt A, Demylle D, Wyns C, et al. Comparison of G1.2/G2.2 and Sydney IVF cleavage/blastocyst sequential media for the culture of human embryos: a prospective, randomized, comparative study. Fertil Steril. 2001;76(5):1023-31. Full Text: Exclude Q3-Not RCT. [pmid: 11704128].
Van Montfoort AP, Dumoulin JC, Kester AD, et al. Early cleavage is a valuable addition to existing embryo selection parameters: a study using single embryo transfers. Hum Reprod. 2004;19(9):2103-8. Full Text: Exclude Q3-Not RCT. [pmid: 15243008].
van Montfoort AP, Dumoulin JC, Land JA, et al. Elective single embryo transfer (eSET) policy in the first three IVF/ICSI treatment cycles. Hum Reprod. 2005;20(2):433-6. Full Text: Exclude Q3-Not RCT. [pmid: 15550492].
van Rumste MME, Evers JLH, Farquhar CM. Intracytoplasmic sperm injection versus conventional techniques for oocyte insemination during in vitro fertilisation in patients with non-male subfertility [Full Review]. Cochrane Database of Systematic Reviews 2003, Issue 2. Art. No.: CD001301. DOI: 10.1002/14651858.CD001301. Full Text: Exclude Q3-Review article (Cochrane)
van Weering HG, Schats R, McDonnell J, et al. Ongoing pregnancy rates in in vitro fertilization are not dependent on the physician performing the embryo transfer. Fertil Steril. 2005;83(2):316-20. Full Text: Exclude Q3-Not RCT. [pmid: 15705368].
van Weert JM, van den Broek J, van der Steeg JW, et al. Patients' preferences for intrauterine insemination or in-vitro fertilization. Reproductive Biomedicine Online. 2007;15(4):422-7. Full Text: Exclude Q4-No outcomes of interest. [pmid: 17908405].
van Wely M, Bayram N, Bossuyt PM, et al. Laparoscopic electrocautery of the ovaries versus recombinant FSH in clomiphene citrate-resistant polycystic ovary syndrome. Impact on women's health-related quality of life. Hum Reprod. 2004;19(10):2244-50. Full Text: Exclude Q2-No pregnancy outcome. [pmid: 15242999].
van Wely M, Bayram N, van der Veen F, et al. An economic comparison of a laparoscopic electrocautery strategy and ovulation induction with recombinant FSH in women with clomiphene citrate-resistant polycystic ovary syndrome. Hum Reprod. 2004;19(8):1741-5. Full Text: Exclude Q2-No pregnancy outcome. [pmid: 15166128].
van Wely M, Westergaard LG, Bossuyt PM, et al. Effectiveness of human menopausal gonadotropin versus recombinant follicle-stimulating hormone for controlled ovarian hyperstimulation in assisted reproductive cycles: a meta-analysis. Fertil Steril. 2003;80(5):1086-93. Full Text: Exclude Q3-Review article. [pmid: 14607553].
Van Wely M, Westergaard LG, Bossuyt PMM, et al. Human menopausal gonadotropin versus recombinant follicle stimulation hormone for ovarian stimulation in assisted reproductive cycles [Full Review]. Cochrane Database of Systematic Reviews 2003, Issue 1. Art. No.: CD003973. DOI: 10.1002/14651858.CD003973. Full Text: Exclude Q3-Review article (Cochrane).
Vanderzwalmen P, Bertin G, Debauche Ch, et al. Vitrification of human blastocysts with the Hemi-Straw carrier: application of assisted hatching after thawing. Hum Reprod. 2003;18(7):1504-11. Full Text: Exclude Q3-Not RCT. [pmid: 12832379].
Vanky E, Salvesen KA, Heimstad R, et al. Metformin reduces pregnancy complications without affecting androgen levels in pregnant polycystic ovary syndrome women: results of a randomized study. Hum Reprod. 2004;19(8):1734-40. Full Text: Exclude-Not relevant to any question. [pmid: 15178665].
Veeck LL. Does the developmental stage at freeze impact on clinical results post-thaw?. Reproductive Biomedicine Online. 2003;6(3):367-74. Full Text: Exclude Q3-Not RCT. [pmid: 12735876].
Venn A, Jones P, Quinn M, et al. Characteristics of ovarian and uterine cancers in a cohort of in vitro fertilization patients. Gynecol Oncol. 2001;82(1):64-8. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 11426963].
Verhaak CM, Smeenk JM, Evers AW, et al. Women's emotional adjustment to IVF: a systematic review of 25 years of research. Hum Reprod Update. 2007;13(1):27-36. Full Text: Exclude Q4-Review article. [pmid: 16940360].
Verheyen G, Vernaeve V, Van Landuyt L, et al. Should diagnostic testicular sperm retrieval followed by cryopreservation for later ICSI be the procedure of choice for all patients with non-obstructive azoospermia?. Hum Reprod. 2004;19(12):2822-30. Full Text: Exclude Q3-Not RCT. [pmid: 15492024].
Verhulst SM, Cohlen BJ, Hughes E, et al. Intra-uterine insemination for unexplained subfertility [Full Review]. Cochrane Database of Systematic Reviews 2006, Issue 4. Art. No.: CD001838. DOI: 10.1002/14651858.CD001838.pub3. Full Text: Exclude Q3-Review article (Cochrane).
Vermeylen AM, D'Hooghe T, Debrock S, et al. The type of catheter has no impact on the pregnancy rate after intrauterine insemination: a randomized study. Hum Reprod. 2006;21(9):2364-7. Full Text: Exclude-Not relevant to any question. [pmid: 16704994].
Vernaeve V, Krikilion A, Verheyen G, et al. Outcome of testicular sperm recovery and ICSI in patients with non-obstructive azoospermia with a history of orchidopexy. Hum Reprod. 2004;19(10):2307-12. Full Text: Exclude Q3-Not RCT. [pmid: 15310729].
Vidaeff AC, Racowsky C, Rayburn WF. Blastocyst transfer in human in vitro fertilization. A solution to the multiple pregnancy epidemic. J Reprod Med. 2000;45(7):529-39. discussion 539–40. Full Text: Exclude Q3-Not RCT. [pmid: 10948462].
Virant-Klun I, Tomazevic T, Zorn B, et al. Blastocyst formation—good indicator of clinical results after ICSI with testicular spermatozoa. Hum Reprod. 2003;18(5):1070-6. Full Text: Exclude Q3-Not RCT. [pmid: 12721186].
Vitiello D, Patrizio P. Implantation and early embryonic development: implications for pregnancy. Semin Perinatol. 2007;31(4):204-7. Full Text: Exclude Q4-Background article. [pmid: 17825673].
Vlaisavljevic V, Kovacic B, Reljic M, et al. Three protocols for monitoring follicle development in 587 unstimulated cycles of in vitro fertilization and intracytoplasmic sperm injection. A comparison. J Reprod Med. 2001;46(10):892-8. Full Text: Exclude Q3-Not RCT. [pmid: 11725733].
Wald M, Sparks AE, Sandlow J, et al. Computational models for prediction of IVF/ICSI outcomes with surgically retrieved spermatozoa. Reproductive Biomedicine Online. 2005;11(3):325-31. Full Text: Exclude Q3-Not RCT. [pmid: 16176672].
Waldenstrom U, Hellberg D, Nilsson S. Low-dose aspirin in a short regimen as standard treatment in in vitro fertilization: a randomized, prospective study. Fertil Steril. 2004;81(6):1560-4. Full Text: Exclude Q3-Data not per patient. [pmid: 15193477].
Wang JX, Davies MJ, Norman RJ. Obesity increases the risk of spontaneous abortion during infertility treatment. Obesity Research. 2002;10(6):551-4. Full Text: Exclude Q4-Data duplicate of #3420. [pmid: 12055331].
Wang JX, Norman RJ, Wilcox AJ. Incidence of spontaneous abortion among pregnancies produced by assisted reproductive technology. Hum Reprod. 2004;19(2):272-7. Full Text: Exclude Q4-Invalid data. [pmid: 14747166].
Wang JX, Yap YY, Matthews CD. Frozen-thawed embryo transfer: influence of clinical factors on implantation rate and risk of multiple conception. Hum Reprod. 2001;16(11):2316-9. Full Text: Exclude Q3-Not RCT. [pmid: 11679511].
Wang PT, Lee RK, Su JT, et al. Cessation of low-dose gonadotropin releasing hormone agonist therapy followed by high-dose gonadotropin stimulation yields a favorable ovarian response in poor responders. J Assist Reprod Genet. 2002;19(1):1-6. Full Text: Exclude Q2-Not RCT; Full Text: Exclude Q3-Not RCT. [pmid: 11893009].
Wang W, Check JH, Liss JR, et al. A matched controlled study to evaluate the efficacy of acupuncture for improving pregnancy rates following in vitro fertilization-embryo transfer. Clin Exp Obstet Gynecol. 2007;34(3):137-8. Full Text: Exclude Q3-Not RCT. [pmid: 17937084].
Wang YA, Sullivan EA, Black D, et al. Preterm birth and low birth weight after assisted reproductive technology-related pregnancy in Australia between 1996 and 2000. Fertil Steril. 2005;83(6):1650-8. Full Text: Exclude Q4-No relevant data. [pmid: 15950632].
Watts P, Adams GG. In vitro fertilisation and stage 3 retinopathy of prematurity. Eye. 2000;14(Pt 3A):330-3. Full Text: Exclude Q4-No relevant data. [pmid: 11026994].
Weissenberg R, Landau R, Madgar I. Older single mothers assisted by sperm donation and their children. Hum Reprod. 2007;22(10):2784-91. Full Text: Exclude Q4-Donor sperm. [pmid: 17675354].
Weisz B, Rodeck CH. An update on antenatal screening for Down's syndrome and specific implications for assisted reproduction pregnancies. Hum Reprod Update. 2006;12(5):513-8. Full Text: Exclude Q4-Background article. [pmid: 16672245].
Wennerholm UB, Bergh C, Hamberger L, et al. Incidence of congenital malformations in children born after ICSI. Hum Reprod. 2000;15(4):944-8. Full Text: Exclude Q4-No 2×2 table. [pmid: 10739847].
Wennerholm UB, Bergh C, Hamberger L, et al. Obstetric outcome of pregnancies following ICSI, classified according to sperm origin and quality. Hum Reprod. 2000;15(5):1189-94. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 10783376].
Westergaard HB, Johansen AM, Erb K, et al. Danish National IVF Registry 1994 and 1995. Treatment, pregnancy outcome and complications during pregnancy. Acta Obstet Gynecol Scand. 2000;79(5):384-9. Full Text: Exclude Q4-Non U.S., no controls. [pmid: 10830766].
Westlander G, Rosenlund B, Soderlund B, et al. Sperm retrieval, fertilization, and pregnancy outcome in repeated testicular sperm aspiration. J Assist Reprod Genet. 2001;18(3):171-7. Full Text: Exclude Q3-Not RCT. [pmid: 11411434].
Westphal LM, Hinckley MD, Behr B, et al. Effect of ICSI on subsequent blastocyst development and pregnancy rates. J Assist Reprod Genet. 2003;20(3):113-6. Full Text: Exclude Q3-Not RCT. [pmid: 12735386].
Wilcox AJ, Baird DD, Weinberg CR. Time of implantation of the conceptus and loss of pregnancy. N Engl J Med. 1999;340(23):1796-9. Full Text: Exclude Q4-Background article. [pmid: 10362823].
Wilcox AJ, Weinberg CR, O'Connor JF, et al. Incidence of early loss of pregnancy. N Engl J Med. 1988;319(4):189-94. Full Text: Exclude Q4-Background article. [pmid: 3393170].
Wild MD, Roudebush WE. Platelet-activating factor improves intrauterine insemination outcome. Am J Obstet Gynecol. 2001;184(6):1064-5. Full Text: Exclude Q3-Not RCT. [pmid: 11349157].
Williams RS, Hillard JB, De Vane G, et al. A randomized, multicenter study comparing the efficacy of recombinant FSH vs recombinant FSH with Ganirelix during superovulation/IUI therapy. Am J Obstet Gynecol. 2004;191(2):648-51. discussion 651–3. Full Text: Exclude Q2-Data not per patient. [pmid: 15343256].
Williams RS, Vensel T, Sistrom CL, et al. Pregnancy rates in varying age groups after in vitro fertilization: a comparison of follitropin alfa (Gonal F) and follitropin beta (Follistim). Am J Obstet Gynecol. 2003;189(2):342-6. discussion 346–7. Full Text: Exclude Q3-Not RCT. [pmid: 14520188].
Williams SC, Gibbons WE, Muasher SJ, et al. Minimal ovarian hyperstimulation for in vitro fertilization using sequential clomiphene citrate and gonadotropin with or without the addition of a gonadotropin-releasing hormone antagonist. Fertil Steril. 2002;78(5):1068-72. Full Text: Exclude Q3-Not RCT. [pmid: 12413995].
Wilson M, Hartke K, Kiehl M, et al. Integration of blastocyst transfer for all patients. Fertil Steril. 2002;77(4):693-6. Full Text: Exclude Q3-Not RCT. [pmid: 11937117].
Wilson M, Hartke K, Kiehl M, et al. Transfer of blastocysts and morulae on day 5. Fertil Steril. 2004;82(2):327-33. Full Text: Exclude Q3-Donor egg. [pmid: 15302279].
Windt ML, Coetzee K, Kruger TF, et al. Intracytoplasmic sperm injection with testicular spermatozoa in men with azoospermia. J Assist Reprod Genet. 2002;19(2):53-9. Full Text: Exclude Q3-Not RCT. [pmid: 11958505].
Windt ML, Kruger TF, Coetzee K, et al. Comparative analysis of pregnancy rates after the transfer of early dividing embryos versus slower dividing embryos. Hum Reprod. 2004;19(5):1155-62. Full Text: Exclude Q3-Not RCT. [pmid: 15044410].
Woldringh GH, Kremer JA, Braat DD, et al. Intracytoplasmic sperm injection: a review of risks and complications. BJU International. 2005;96(6):749-53. Full Text: Exclude Q3-Not RCT. [pmid: 16153192].
Wolf DP, Patton PE, Burry KA, et al. Intrauterine insemination-ready versus conventional semen cryopreservation for donor insemination: a comparison of retrospective results and a prospective, randomized trial. Fertil Steril. 2001;76(1):181-5. Full Text: Exclude Q2-Donor sperm. [pmid: 11438340].
Wood HP, Trock BP, Gearhart JP. In vitro fertilization and the cloacal-bladder exstrophy-epispadias complex: is there an association?. J Urol. 2003;169(4):1512-5. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 12629406].
Wood S, Sephton V, Searle T, et al. Effect on clinical outcome of the interval between collection of epididymal and testicular spermatozoa and intracytoplasmic sperm injection in obstructive azoospermia. J Androl. 2003;24(1):67-72. Full Text: Exclude Q3-Not RCT. [pmid: 12514085].
Wood S, Thomas K, Schnauffer K, et al. Reproductive potential of fresh and cryopreserved epididymal and testicular spermatozoa in consecutive intracytoplasmic sperm injection cycles in the same patients. Fertil Steril. 2002;77(6):1162-6. Full Text: Exclude Q3-Not RCT. [pmid: 12057722].
Wright VC, Chang J, Jeng G, et al. Assisted reproductive technology surveillance—United States, 2003. Morbidity & Mortality Weekly Report. Surveillance Summaries. 2006;55(4):1-22. Full Text: Exclude-Not relevant to any question. [pmid: 16723970].
Wright VC, Chang J, Jeng G, et al. Assisted reproductive technology surveillance - United States, 2004. Morbidity & Mortality Weekly Report. Surveillance Summaries. 2007;56(6):1-22. Full Text: Exclude-Not relevant to any question. [pmid: 17557073].
Wright VC, Schieve LA, Reynolds MA, et al. Assisted reproductive technology surveillance—United States, 2002. MMWR. Surveillance Summaries: Morbidity & Mortality Weekly Report. Surveillance Summaries/CDC. 2005;54(2):1-24. Full Text: Exclude Q3-Not RCT; Full Text: Exclude Q4-No controls.
Wright VC, Schieve LA, Reynolds MA, et al. Assisted reproductive technology surveillance—United States, 2001. MMWR. Surveillance Summaries: Morbidity & Mortality Weekly Report. Surveillance Summaries/CDC. 2004;53(1):1-20. Full Text: Exclude Q4-Data not per patient.
Xavier P, Gamboa C, Calejo L, et al. A randomised study of GnRH antagonist (cetrorelix) versus agonist (busereline) for controlled ovarian stimulation: effect on safety and efficacy. Eur J Obstet Gynecol Reprod Biol. 2005;120(2):185-9. Full Text: Exclude Q2-Data not per patient. [pmid: 15925049].
Yano K, Yano C, Kubo T, et al. Chemical zona pellucida thinning with acidified Tyrode's solution: comparison between partial and circumferential techniques. J Assist Reprod Genet. 2007;24(10):471-5. Full Text: Exclude Q3-Data not per patient. [pmid: 17701000].
Yavas Y, Selub MR. Intrauterine insemination (IUI) pregnancy outcome is enhanced by shorter intervals from semen collection to sperm wash, from sperm wash to IUI time, and from semen collection to IUI time. Fertil Steril. 2004;82(6):1638-47. Full Text: Exclude Q3-Not RCT. [pmid: 15589871].
Yoeli R, Ashkenazi J, Orvieto R, et al. Pregnancy potential of embryos from in vitro fertilization compared to intracytoplasmic sperm injection. Gynecol Endocrinol. 2000;14(4):253-7. Full Text: Exclude Q3-Not RCT. [pmid: 11075295].
Yoon HG, Yoon SH, Son WY, et al. Alternative embryo transfer on day 3 or day 5 for reducing the risk of multiple gestations. J Assist Reprod Genet. 2001;18(5):262-7. Full Text: Exclude Q3-Not RCT. [pmid: 11464577].
Young P, Purdie D, Jackman L, et al. A study of infertility treatment and melanoma. Melanoma Res. 2001;11(5):535-41. Full Text: Exclude-Not relevant to any question. [pmid: 11595893].
Yuzpe AA, Liu Z, Fluker MR. Rescue intracytoplasmic sperm injection (ICSI)-salvaging in vitro fertilization (IVF) cycles after total or near-total fertilization failure. Fertil Steril. 2000;73(6):1115-9. Full Text: Exclude Q3-Not RCT. [pmid: 10856467].
Zech NH, Lejeune B, Puissant F, et al. Prospective evaluation of the optimal time for selecting a single embryo for transfer: day 3 versus day 5. Fertil Steril. 2007;88(1):244-6. Full Text: Exclude Q3-Not RCT. [pmid: 17292362].
Zenke U, Jalalian L, Shen S, et al. The difficult MESA: findings from tubuli recti sperm aspiration. J Assist Reprod Genet. 2004;21(2):31-5. Full Text: Exclude Q3-Not RCT. [pmid: 15186019].
Zhivkova RS. Ploidity and chromatin status of human oocytes after failed in vitro fertilization. Eur J Obstet Gynecol Reprod Biol. 2003;109(2):185-9. Full Text: Exclude-Not relevant to any question. [pmid: 12860339].
Zhu WJ, Li XM, Chen XM, et al. Follicular aspiration during the selection phase prevents severe ovarian hyperstimulation in patients with polycystic ovary syndrome who are undergoing in vitro fertilization. Eur J Obstet Gynecol Reprod Biol. 2005;122(1):79-84. Full Text: Exclude Q3-Not RCT. [pmid: 16154042].
Zuppa AA, Scorrano A, Cota F, et al. Neonatal outcomes in triplet pregnancies: assisted reproduction versus spontaneous conception. J Perinat Med. 2007;35(4):339-43. Full Text: Exclude Q4-N < 100 (not RCT). [pmid: 17614752].