# Appendix A: Exact Search String

Database: Ovid MEDLINE^®^ (1966 to August Week 2 2005)

Later updated through January Week 4 2008

Search Strategy:

--------------------------------------------------------------------------------

1 *reproductive techniques/ or *reproductive techniques, assisted/ or *embryo transfer/ or exp *fertilization in vitro/ or *gamete intrafallopian transfer/ or *oocyte donation/ or *zygote intrafallopian transfer/ (17110)
2 *fertility agents/ or *fertility agents, female/ or *clomiphene/ or *menotropins/ or *metformin/ (5216)
3 exp *insemination, artificial/ or exp *ovulation induction/ (7431)
4 Pregnancy Outcome/ (19904)
5 exp Pregnancy Complications/ (225332)
6 pregnancy rate/ or birth rate/ (8686)
7 Ovarian Hyperstimulation Syndrome/ (981)
8 exp Ovarian Neoplasms/ (39423)
9 exp Endometrial Neoplasms/ (7690)
10 exp Breast Neoplasms/ (124437)
11 “Quality of Life”/ (47871)
12 Cesarean Section/ (21813)
13 exp Pregnancy, Multiple/ or Twins/ (19011)
14 exp ABNORMALITIES/ (292667)
15 exp Infant, Newborn, Diseases/ (109923)
16 Fetal Growth Retardation/ (8564)
17 (or/1–3) and (or/4–16) (6491)
18 limit 17 to (humans and english language) (5300)
19 Preimplantation Diagnosis/ (910)
20 18 not 19 (5240)
21 limit 20 to yr=“1990 - 2005” (4551)
22 limit 21 to yr=“1995 - 2005” (3738)
23 limit 22 to “review articles” (367)
24 22 not 23 (3371)
25 from 24 keep 1–10 (10)
26 prevalence/ or risk factors/ (328058)
27 exp *infertility/ or *anovulation/ (24278)
28 26 and 27 (728)
29 infertility/ep or anovulation/ep (314)
30 28 or 29 (979)
31 embryo research/ or research embryo creation/ or laparoscopy/ or hysterosalpingography/ or hysteroscopy/ or ultrasonography/ (87033)
32 infertility/ or anovulation/ (6919)
33 31 and 32 (249)
34 30 or 33 (1219)
35 limit 34 to (humans and english language) (938)
36 35 not 19 (937)
37 limit 36 to yr=“1990 - 2005” (769)
38 limit 37 to yr=“1995 - 2005” (548)
39 21 or 37 (5257)
40 22 or 38 (4239)
41 limit 40 to “review articles” (491)
42 40 not 41 (3748)
43 limit 39 to “review articles” (602)
44 39 not 43 (4655)
45 limit 44 to abstracts (3853)
46 limit 42 to abstracts (3155)
47 45 not 46 (698)
48 from 47 keep 1–698 (698)
49 limit 46 to yr=“1995 - 1999” (1388)
50 limit 46 to yr=“2000 - 2002” (888)
51 limit 46 to yr=“2003 - 2005” (879)
52 from 49 keep 1–1388 (1388)
53 from 50 keep 1–888 (888)
54 from 51 keep 1–879 (879)