# Appendix F. Evidence Tables

Table F1 Characteristics of study population and study setting in studies assessing the effectiveness of diabetes education for children with type 1 diabetes and their families

Author Year | Sample Size (n) Study Design Location | Age, Mean±SD % Male | Duration of Diabetes, Mean±SD HbA1c at Baseline, Mean±SD | Other Characteristics | Intervention Setting
Anderson^5^ 1999 | 89 RCT (parallel) United States | IG1 12.7 yr. ±1.40 50% IG2 12.7 yr. ±1.40 50% CG 12.5 yr. ±1.4 52% | IG1 5.3 yr. ±2.56 8.3%±1.10 IG2 6.1 yr. ±2.78 8.7%±1.19 CG 5.2 yr. ±2.17 8.6%±0.97 | Duration of diabetes >1 yr. | IG1 - Diabetes responsibilities IG2 - Didactic diabetes education CG - Standard care Diabetes center
Anderson^6^ 1989 | 70 RCT (parallel) United States | IG 12.9 yr. 46.7% CG 12.5 yr. 46.7% | IG 4.9 yr. ±3.2 10.47%±2.30 CG 5.1 yr. ±3.3 10.42%±1.9 | Duration of diabetes >1 yr. | IG - Self-management skills, problem solving CG - Standard care Clinic
Barglow^7^ 1983 | 42 CCT United States | IG 13.4 yr. ±3.3 43% CG 12.2 yr. ±2.5 24% | IG 4.9 yr. ±3.8 12.2%±2.3 CG 3.2 yr. ±3.0 12.1%±3.5 | | IG - Intensive treatment CG - Standard care Diabetes center
Boardway^8^ 1993 | 31 RCT (parallel) United States | IG 15.44 yr. ±1.19 22.2% CG 14.32 yr. ±1.71 60.0% | IG 6.92 yr. ±5.79 13.99%±2.41 CG 6.34 yr. ±2.61 15.74%±3.57 | Noncompliance and/or poor metabolic control | IG - Stress management plus self-management skills CG - Standard care Outpatient clinic
Brown^9^ 1997 | 59 RCT (parallel) United States | IG NR CG NR | IG NR 8.47%±1.64 CG NR 8.28%±1.89 | Duration of diabetes >3 mo. | IG - Diabetes video game CG - Pinball video game Home
Campaigne^10^ 1985 | 16 RCT (parallel) United States | IG 16.0 yr. ±3 33.3% CG 15.0 yr. ±0.9 60.0% | IG 6.6 yr. ±3.3 12.0%±3.0 CG 6.2 yr. ±2.5 12.0%±2.2 | | IG - Exercise sessions CG - Standard care NR
Caravalho^11^ 2000 | 56 Uncontrolled before-and-after study United States | IG 9.8 yr. 45% | IG 3 yr. 9.15%±2.32 | | IG - Self-management skills, telephone assessments Home, diabetes center
Christensen^12^ 2000 | 68 Uncontrolled before-and-after study United States | IG NR 47.1% | IG 5.04 yr. 9.6% | | IG - Nutrition and diet Camp
Cigrang^13^ 1991 | 37 RCT (parallel) United States | IG1 14.6 yr. ±1.6 46.7% IG2 13.5 yr. ±1.7 30.8% CG 13.9 yr. ±1.4 55.6% | IG1 4.9 yr. ±2.9 9.07%±0.88 IG2 4.5 yr. ±2.9 9.92%±2.2 CG 6.7 yr. ±3.5 8.91%±1.2 | Poor metabolic control | IG1 - Stress coping strategies IG2 - Diabetes lectures CG - Standard care Hospital
Couper^14^ 1999 | 69 CCT Australia | IG 14.2 yr. ±1.7 48.6% CG 14.3 yr. ±1.9 31.3% | IG 7.08 yr. ±3.6 11.1%±1.3 CG 5.83 yr. ±3.0 10.5%±1.6 | Poor metabolic control | IG - Goal setting CG - Standard care Hospital, home
Coupland^15^ 1992 | 32 RCT (parallel) Canada | IG 14.5 yr. ±1.41 53% CG 14.7 yr. ±1.75 33% | IG 4.80 yr. ±2.59 11.6%±1.4 CG 6.64 yr. ±3.02 11.3%±1.22 | Noncompliance and/or poor metabolic control | IG - General diabetes knowledge and family adherence CG - General diabetes knowledge, stress coping NR
Delamater^16^ 1991 | 13 RCT (parallel) United States | IG1 NR 33% CG NR 57% TG 14.9 yr. 46% | IG NR CG NR TG 6.5 yr. range: 2.5–15 yr. 10.9%±1.6 | Noncompliance and/or poor metabolic control | IG - Self-management skills, psychosocial skills CG - Standard care Hospital outpatient clinic
Delamater^17^ 1990 | 36 RCT (parallel) United States | IG1 9.3 yr. ±3.9 58% IG2 8.6 yr. ±4.1 50% CG 9.8 yr. ±2.6 50% | IG1 < 4 mo. 10.4%±3.1 IG2 < 4mo. 11.1%±2.4 CG < 4 mo 12.3%±2.5 | Newly diagnosed | IG1 - Self-management skills and problem solving IG2 - Psychosocial adjustment CG - Standard care Hospital, home
Dougherty^18^ 1999 | 63 RCT (parallel) Canada | IG 10.7 yr. ±3.9 40.6% CG 9.8 yr. ±3.9 48.4% | IG 0 yr. 10.0%±2.0 CG 0 yr. 10.7%±1.3 | Newly diagnosed | IG - General diabetes knowledge (in home) CG - General diabetes knowledge (in hospital) Hospital, home
Golden^19^ 1985 | 19 CCT United States | IG1 2.7 yr. 54.54% IG2 NR 62.5% | IG1 NR IG2 NR | Newly diagnosed | IG1 - Diabetes management in motel-like setting IG2 - Delayed IG1 Diabetes center, parent care unit, a motel-like setting
Greco^20^ 2001 | 23 Uncontrolled before-and-after study United States | IG 13.1 yr. ±1.98 52.38% IG (Peer) 13.6 yr. ±2.25 52.38% | IG 0.7025 yr. ±0.385 NR IG (Peer) NA | | IG - General diabetes knowledge, listening and problem solving skills, stress management IG (Peer) - a “best friend” received the same intervention Outpatient clinic
Grey^21^ 2000 | 77 RCT (parallel) United States | IG 14.1 yr. ±1.8 48.8% CG 14.6 yr. ±2.2 35.3% | IG NR 9.1%±1.4 CG NR 9.2%±1.5 | Duration of diabetes >1 yr. | IG - Coping skills training CG - Standard care Hospital, home
Gross^22^ 1985 | 14 RCT (parallel) United States | IG 11.4 yr. 57.14% CG 11.5 yr. 28.57% TG 11.4 yr. 42.85% | IG NR CG NR TG 4.8 yr. | ≥3 deficit social skill behaviors | IG - Behavior modification CG - Open-ended discussion NR
Gross^23^ 1983 | 11 RCT (parallel) United States | IG NR | IG NR | | IG - Social training CG - No social training Treatment room
Hackett^24^ 1989 | 119 RCT (parallel) United Kingdom | IG1 12.7 yr. ±2.9 62.5% IG2 11.4 yr. ±3.3 65.5% IG3 12.4 yr. ±3.6 53.1% CG 11.7 yr. ±3.3 69.2% | IG1 4.6 yr. ±2.9 11.1%±2.7 IG2 5.9 yr. ±2.8 11.2%±1.7 IG3 5.3 yr. ±3.2 11.0%±2.3 CG 5.0 yr. ±3.1 10.8%±2.1 | | IG1 - General diabetes knowledge and reinforcement sessions IG2 - General diabetes knowledge IG3 - General diabetes knowledge, 10 mo. after IG1 and IG2 CG - No intervention Clinic
Hains^25^ 2000 | 15 RCT (parallel) United States | IG NR 37.5% CG NR 50.0% | IG NR 10.06%±1.07 CG NR 9.95%±1.42 | Poor metabolic control | IG - Cognitive behavioral stress training CG - No intervention Hospital
Hakimi^26^ 1998 | 35 RCT (parallel) United States | IG 11.4 yr. ±2.5 26.7% CG 11.7 yr. ±2.7 55.5% TG 11.5 yr. ±2.5 37.5% | IG 0 yr. NR CG 0 yr. NR TG 0 yr. NR | Newly diagnosed | IG - General diabetes knowledge plus psychosocial issues CG - General diabetes knowledge NR
Harkavy^27^ 1983 | 93 Uncontrolled before-and-after study United States | IG 13.2 yr. 48% | IG 4.7 yr. NR | | IG - General diabetes education Camp
Harris^28^ 2005 | 18 Uncontrolled before-and-after study United States | IG 67 yr. NR | IG 14.7 11.3%±1.5 | Noncompliance and/or poor metabolic control | IG - Behavioral family systems therapy Home
Hill^29^ 2006 | 134 Prospective cohort with concurrent control United States | IG NR CG NR 50% TG NR 50% | IG NR CG NR TG NR | | IG - General diabetes knowledge, choice and sense of self-control CG - Regular camp Camp
Hoff^30^ 2005 | 46 RCT (parallel) United States | IG 9.3 yr. ±4.7 47% CG 9.4 yr. ±3.4 59% TG 9.4 yr. ±4.1 53% | IG < 6mo. NR CG < 6 mo. NR TG < 6 mo. NR | Newly diagnosed | IG - Construct of illness, uncertainty management CG - Standard care Hospital endocrinology clinic
Horan^31^ 1990 | 20 RCT (parallel) United States | IG NR 30.0% CG NR 30.0% | IG NR 10.0% CG NR 9.6% | Duration fo diabetes >1 yr. | IG - Dynamic and colourful education modules CG - Static, black-and-white education modules Home
Howe^32^ 2005 | 89 RCT (parallel) United States | IG1 13.6 yr. ±2.0 57.1% IG2 12.1 yr. ±4.0 50.0% CG 12.2 yr. ±3.7 57.1% | IG1 NR 10.1%±1.2 IG2 NR 10.0%±1.4 CG NR 10.2%±1.4 | | IG1 - General diabetes knowledge (family session) IG2 - IG1 plus telephone calls CG - Standard care Diabetes center, home
Kaplan^33^ 1985 | 21 RCT (parallel) United States | IG 14.9 yr. ±1.6 40% CG 14.0 yr. ±1.4 36.4% | IG NR 12.6%±2.4 CG NR 13.5%±1.6 | | IG - Social skills training CG - General diabetes knowledge (lectures) Summer school
Karaguzel^34^ 2005 | 25 Uncontrolled before-and-after study Turkey | IG 13.2 yr. ±2.6 36% | IG 5.0 yr. ±4.1 9.28%±2.46 | Moderate-poor metabolic control | IG - General diabetes education Camp
Kemp^35^ 1986 | 42 Uncontrolled before-and-after study United States | IG 10 yr. NR | IG NR 8.1%±1.9 | | IG - General diabetes education Camp
Kennedy-Iwai^36^ 1991 | 19 RCT (parallel) United States | IG 6.0 yr. ±3.2 NR CG 7.1 yr. ±4.4 NR | IG 0.75 yr. ±0.41 9.72%±2.73 CG 0.78 yr. ±0.43 8.69%±2.40 | Newly diagnosed | IG - Communication program for parents CG - General diabetes education Home
Koontz^37^ 2001 | 112 Uncontrolled before-and-after study United States | IG1 NR 30.8% IG2 NR 35.2% IG3 NR 44.4% | IG1 5.85 yr. ±4.26 8.32%±1.60 IG2 5.56 yr. ±3.45 8.93%±2.06 IG3 4.22 yr. ±2.62 7.99%±1.42 | | IG1 - General diabetes knowledge (grades 9–10) IG2 - General diabetes knowledge (grades 6–8) IG3 - General diabetes knowledge (grades 2–5) Camp
Laffel^38^ 2003 | 105 RCT (parallel) United States | IG 11.9 yr. ±2.4 54% CG 12.2 yr. ±2.2 52% | IG 2.7 yr. ±1.6 8.4%±1.3 CG 2.7 yr. ±1.6 8.3%±1.0 | | IG - General diabetes education, responsibility sharing CG - Standard care Diabetes center, home
Lawson^39^ 2000 | 28 Retrospective cohort Canada | IG1 15.8 yr. ±4.0 NR IG2 15.0 yr. ±1.8 NR | IG1 7.7 yr. ±1.7 9.5%±1.2 IG2 6.8 yr. ±2.9 8.2%±1.3 | Motivated to improve metabolic control | IG1 - 6–8 hours, general diabetes knowledge, telephone calls IG2 - 4 hours, general diabetes knowledge Diabetes center, home
Likitmaskul^40^ 2002 | 52 Prospective cohort with historical control Thailand | IG 7.07 yr. ±3.87 45.8% CG 8.4 yr. ±3.26 35.7% | IG 0 yr. 17.42% CG 0 yr. 13.56% | Newly diagnosed | IG - Self-management skills, hypoglycemia CG - Standard care Hospital
Lipman^41^ 1988 | 30 Retrospective cohort United States | IG 7.4 yr. ±4.3 81.8% IG 7.4 yr. ±3.5 69.2% | IG 0 yr. NR CG 0 yr. NR | Newly diagnosed | IG - Clinical nurse specialist plus staff nurses deliver education CG - Staff nurses deliver education Hospital
Lucey^42^ 1985 | 49 CCT United Kingdom | IG 11.7 yr. 50% CG 12.25 yr NR | IG NR CG NR | Poor theoretical and practical diabetes skills | IG - General diabetes knowledge, problem solving CG - No intervention NR
Mann^43^ 1984 | 39 RCT (parallel) United Kingdom | IG1 11.2 yr. ±2.7 65% IG2 12.3 yr. ±2.2 52.6% | IG1 5.9 yr. ±3.3 12.7%±2.0 IG2 5.6 yr. ±3.2 14.1%±1.3 | Poor metabolic control | IG1 - Home visits, instructional videos, telephone contact IG2 - IG1 plus graphically tracking of BG data Home, community, outpatient clinic
Marteau^44^ 1987 | 97 Uncontrolled before-and-after study United Kingdom | IG 10.7 yr. 27.8% | IG NR | | IG - Problem solving, self-help groups, best care Hotel
Mason^45^ 1985 | 93 CCT United States | IG NR CG NR | IG NR CG NR | | IG - Diabetes board game CG - Same as IG (non-diabetic) School, diabetes center
Massouh^46^ 1989 | 33 RCT (parallel) United States | IG 12.6 yr. ±0.712 41.1% CG 13.1 yr. ±0.987 50% | IG 3.9 yr. ±3.1 11.3%±3.3 CG 4.7 yr. ±3.5 11.5%±3.6 | | IG - General diabetes knowledge, plus social learning intervention CG - General diabetes knowledge Camp
McNabb^47^ 1994 | 24 RCT (parallel) United States | IG 9.7 yr. NR CG 10 yr. NR TG 9.9 yr. 54% | IG NR 10.5%±2.9 CG NR 12.9%±3.8 TG NR | | IG - Goal-setting, self-management (youths), parenting skills (parents) CG - Standard care Diabetes center
Mendez^48^ 1997 | 37 CCT Spain | IG 13.83 yr. ±2.00 50% CG 13.36 yr. ±1.89 47% | IG 3.73 yr. ±3.93 NR CG 4.46 yr. ±3.52 NR | | IG - Adherence behaviors CG - No data Health centre
Mitchell^49^ 1996 | 32 RCT (parallel) Canada | IG 10.43 yr. ±2.44 53.3% CG 11.0 yr. ±2.35 58.8% | IG 0 yr. 7.0% CG 0 yr. 8.0% | Newly diagnosed | IG - Adherence behaviors IG - Standard care Diabetes center
Monaco^50^ 1996 | 58 Uncontrolled before-and-after study United States | IG 8.5 yr. 50% | IG NR | | IG - Injection site identification Diabetes center
Moran^51^ 1991 | 22 CCT United Kingdom | IG 13.4 yr. ±3.2 37.4% CG 14.0 yr. ±4.3 37.4% | IG 6.2 yr. ±4.3 14.3% CG 5.6 yr. ±2.3 13.7% | Poor metabolic control | IG - Psychotherapy CG - Standard care (hospital) Hospital, home
Nordfeldt^52^ 2005 | 332 RCT (parallel) Sweden | IG 12.7 yr. ±4.1 45.6% CG1 12.5 yr. ±4.2 44.7% CG2 12.7 yr. ±3.9 45.6% TG 12.2 yr. ±4.1 45.3% | IG 4.9 yr. ±3.5 7.8%±1.4 CG1 5.6 yr. ±4.2 7.8%±1.3 CG2 5.2 yr. ±3.6 8.0%±1.8 TG 5.3 yr. ±3.8 7.9%±1.5 | Duration of diabetes >0.5 yr. | IG - Self-management skills, 2 instructional videos, 2 brochures CG1 - Standard care, 1 video, 1 brochure CG2 - Standard care Home
Nordfeldt^53^ 2002 | 130 Prospective cohort with historical controls Sweden | IG 12.2 yr. ±4.3 NR | IG 4.6 yr. ±3.7 6.6%±1.1 | | IG - Self-management skills, 2 instructional videos, 2 brochures Home
Nordfeldt^54^ 1999 | 139 Prospective cohort with historical controls Sweden | IG 12.9 yr. ±4.4 59% CG NR | IG 5.0 yr. ±3.9 7.0%±1.1 CG 7.4 yr. ±4.9 7.4%±1.1 | | IG - Intense, problem-based training CG - Children diagnosed between 1971 and 1981 receiving standard care Home, community, school, diabetes center
Nunn^55^ 2006 | 123 RCT (parallel) Australia | IG 11.9 yr. ±3.7 55% CG 11.9 yr. ±3.0 57% | IG 3.73 yr. ±2.41 8.15%±1.14 CG 3.58 yr. ±2.36 8.32%±1.01 | Poor metabolic control | IG - General diabetes knowledge (telephone calls) CG - Standard care Home, diabetes center
Olmsted^56^ 2002 | 85 RCT (parallel) Canada | TG 16.0 yr. ±2.0 0% | TG 7.0 yr. ±3.4 9.1%±1.5 | Eating disorder | IG - Eating disorder intervention CG - Standard care Diabetes Center
Panagiotopoulos^57^ 2003 | 50 RCT (parallel) Canada | IG 14.4 yr. ±1.7 44% CG 13.8 yr. ±1.5 36% | IG 7.0 yr. ±3.2 9.7%±1.2 CG 5.5 yr. ±3.1 9.6%±1.3 | Poor metabolic control | IG - Self-management skills (telephone calls) CG - Standard care Home, diabetes center
Pichert^58^ 1994a | 83 RCT (parallel) United States | TG NR | IG 6.1 yr. CG 6.5 yr. range: 6 mo.–15 yr. NR | | TG - Anchored instruction, nutrition education Camp
Pichert^59^ 1994b | 84 RCT (parallel) United States | TG NR 47.6% | TG 6.9 yr. range: 3 mo.–14 yr. NR | | TG - Anchored instruction, sick-day management Camp
Pichert^60^ 1993 | 70 RCT (parallel) United States | TG NR 55.7% | TG 5 yr. NR | | IG - Anchored instruction, problem solving skills CG - Prepared lecture/ discussion/ rehearsal/ instruction sessions Camp
Povlsen^61^ 2005 | 37 Uncontrolled before-and-after study Denmark | IG NR | IG NR 9.2%±1.4 | Ethnic minority | IG - Re-education session, general diabetes knowledge Hospital
Remley^62^ 1999 | 237 CCT United States | IG 14.53 yr. 42% CG 14.15 yr. 47% | IG 5.78 yr. 8.98% CG 5.22 yr. 8.76% | | IG - Assertive communication, nutrition education CG - No intervention Camp
Satin^63^ 1989 | 32 RCT (parallel) United States | IG1 15.0 yr. ±2.4 36.4% IG2 14.9 yr. ±2.8 25% CG 13.7 yr. ±2.7 55.6% TG 14.6 yr. ±2.6 37.5% | IG1 6.3 yr. ±5.1 13.4%±1.3 IG2 5.2 yr. ±3.8 12.6%±0.9 CG 6.3 yr. ±4.3 12.9%±1.4 TG 5.9 yr. ±4.3 NR | | IG1 - Group process and teamwork, adherence IG2 - IG1, simulated diabetes management (parent) CG - No intervention Hospital
Schlundt^64^ 1996 | 86 Uncontrolled before-and-after study United States | IG 12.1 yr. ±1.8 47% | IG 4.5 yr. ±3.1 NR | | IG - Anchored instruction Camp
Shobhana^65^ 1997 | 37 Uncontrolled before-and-after study India | IG NR | IG NR | Duration of diabetes ≥1 yr. | IG - General diabetes knowledge Diabetes center
Siminerio^66^ 1999 | 32 Prospective cohort with concurrent control group United States | IG1 10.1 yr. 62.5% IG2 10.2 yr. 56.25% | IG1 NR IG2 NR | Newly diagnosed | IG1 - General diabetes knowledge (Hospital) IG2 - General diabetes knowledge (outpatient clinic) Hospital, outpatient clinic
Smith^67^ 1993 | 120 Uncontrolled before-and-after study United States | IG 14.9 yr. ±1.4 43% | IG 4.1 yr. ±3.4 NR | | IG - Assertive communication, problem solving and negotiation skills Camp
Smith^68^ 1991 | 108 Uncontrolled before-and-after study United States | IG 14.5 yr. ±1.4 44% | IG 4.5 yr. ±3.5 NR | | IG - Stress and diabetes Camp
Srinivasan^69^ 2004 | 110 Prospective cohort with concurrent control group Australia | IG1 NR IG2 NR | IG1 NR IG2 NR | Newly diagnosed | IG1 - “Survival skills” diabetes knowledge (outpatient) IG2 - Detailed diabetes knowledge progam (hospital) Outpatient day care program, hospital
Sundelin^70^ 1996 | 38 RCT (parallel) Sweden | IG1 8.7 yr. ±3.2 37% CG 8.8 yr. ±2.7 37% | IG1 NR 9.6%±0.14 CG NR 9.8%±0.74 | Newly diagnosed | IG1 - General diabetes knowledge (hospital apartment) CG - General diabetes knowledge (hosptial) Hospital, apartment
Svoren^71^ 2003 | 301 RCT (parallel) United States | IG1 11.8 yr. ±2.4 39% IG2 12.1 yr. ±2.4 42% CG 11.7 yr. ±2.6 49% | IG1 5.1 yr. ±2.9 8.57%±1.35 IG2 5.3 yr. ±3.0 8.68%±1.03 CG 5.3 yr. ±30. 8.72%±1.17 | Duration of diabetes > 6 mo | IG1 - Care ambassador to assist families IG2 - IG1, plus psychoeducation CG - No intervention Diabetes center
Szumowski^72^ 1990 | 27 RCT (parallel) United States | IG 78.1 mo. 45% CG 76.4 mo 60% | IG 3.24 yr. 9.7%±1.2 CG 2.57 yr. 10.0%±1.5 | Duration of diabetes ≥ 1 yr. | IG - Goal-setting, adherence behaviors CG - General diabetes knowledge Outpatient clinic
Templeton^73^ 1988 | 30 Uncontrolled before-and-after study United States | IG 12.7 yr. NR | IG 4.9 yr. NR | | IG - Food choices and SMBG Diabetes center
Thomas-Dobersen^74^ 1993 | 20 CCT United States | IG NR | IG NR | | IG - Self-management (adolescents), parenting and communication skills (parents) CG - Standard treatment NR
Verrotti^75^ 1993 | 30 Uncontrolled before-and-after Italy | IG 15.4 yr. ±0.8 40.0% | IG 1.3 yr. ±0.4 12.0%±2.9 | | IG - General Diabetes knowledge NR
Viner^76^ 2003 | 21 CCT United Kingdom | IG 13.0 yr. 28.6% CG 13.3 yr. 60.0% | IG 6.2 yr. 10.2%±1.4 CG 5.7 yr. 10.0%±1.3 | Poor metabolic control | IG - Systematic focused therapy CG - No intervention NR
von Sengbusch^77^ 2006 | 107 Uncontrolled before-and-after study Germany | IG 11.1 yr. ±2.5 43.9% | IG 4.3 yr. ±3.0 7.9%±1.4 | Duration of diabetes > 6 mo. | IG - Mobile Diabetic Teaching Team, general diabetic knowledge, independence, self-confidence Hospital
Vyas^78^ 1988 | 63 Uncontrolled before-and-after study United Kingdom | IG 8.4 yr. ±2.0 47% CG | IG 3.9 yr. ±2.0 NR | | IG - Self-management and problem solving skills Camp
Wadham^79^ 2005 | 67 RCT (parallel) United Kingdom | IG 12.9 yr. ±2.1 56% | IG 4.9 yr. ±3.25 9.1%±1.25 | | IG - General diabetes knowledge, teamwork, communication, responsibilities CG - No intervention Clinic
Webb^80^ 1999 | 66 RCT (parallel) United States | IG1 NR IG2 NR TG 10.2 yr. ±1.4 34.8% | IG1 NR 8.68%±0.75 IG2 NR 9.52%±1.28 TG 5 yr. ±2.6 | Duration of diabetes >1 yr. | IG1 - Goal setting (5 goal-setting guidelines) IG2 - Goal setting (without guidelines) Outpatient clinic
Wolanski^81^ 1996 | 41 RCT (parallel) Canada | IG NR | IG 4 mo.–12 yr. NR | Poor self-management skills | IG - BGSM skills CG - Usual teaching activities Camp
Wysocki^82^ 2007 | 104 RCT (parallel) United States | IG1 14.4 yr. ±1.9 56% IG2 13.9 yr. ±1.9 58% CG 14.2 yr. ±1.9 50% | IG1 5.5 yr. ±3.2 9.7%±1.6 IG2 5.1 yr. ±3.0 9.6%±1.6 CG 5.9 yr. ±4.0 9.5%±1.5 | Duration of diabetes >2yr. | IG1 - Group meetings emphasized education and social support IG 2 - Behavioral family systems therapy CG - Standard care Diabetes center
Wysocki^83^ 2000 | 119 RCT (parallel) United States | IG1 14.5 yr. ±1.2 39% IG2 14.1 yr. ±1.4 38% CG 14.3 yr. ±1.4 49% | IG1 5.4 yr. ±3.8 NR IG2 4.5 yr. ±3.7 NR CG 5.2 yr. ±3.8 NR | Poor metabolic control, moderate levels of parent-adolescent conflict | IG1 - Behavioral family systems therapy IG2 - Group meetings, emphasized education, and social support CG - Standard care Doctor's office
Zorumski^84^ 1997 | 56 CCT United States | IG 10.2 yr. ±1.67 55.6% CG 10.43 yr. ±1.57 36.4% | IG 2.7 yr. ±2.13 9.93%±2.9 CG 2.79 yr. ±2.37 10.85%±2.14 | | IG - General diabetes knowledge CG - Standard care Day camp, doctor's office

CG = control group; IG = intervention group; NR = not reported; TG = total group

Table F2 Characteristics and effectiveness of studies of diabetes education for children with type 1 diabetes and their families

Author Year | Sample Size (n) Study Design Setting | Intervention | Interventionist Duration of Intervention Followup Interval | Authors' Conclusions
Anderson^5^ 1999 | 89 RCT (parallel) Diabetes center | IG1 - 20–30 min. sessions every 3–4 mo. For 12 mo., parent-teen shared responsibility for diabetes tasks and ways to avoid conflict IG2 - 20–30 min. sessions every 3–4 mo. For 12 mo., didactic diabetes education with no focus on parental involvement CG - Standard care | Research staff (IG1 and IG2); NA (CG) 12 mo. 24 mo. (IG1); 12 mo. (IG2, CG) | HbA1c - No significant differences at 12 mo. Or 24 mo. Pyschosocial (family/social support) - IG reported less deterioration than CG (p<0.07) at 12 mo. Psychosocial (family/social relationships) - IG reported greater decrease in conflict than CG (p<0.02) at 12 mo.
Anderson^6^ 1989 | 70 RCT (parallel) Clinic | IG - Five 3-hr sessions every 3–4 mo. For 18 mo., SMBG in relation to practical skills, puberty, problem solving, exercise and use with intensive therapies CG - Standard care | Endocrinologist, diabetes nurse educator, dietician, social work (IG and CG); Nutritionist, psychologist (IG) 18 mo. Immediate | HbA1c - IG was significantly lower than CG (p = 0.04) Self-monitoring skills - No significant differences
Barglow^7^ 1983 | 42 CCT Diabetes center | IG - Intensive, multi-component treatment individually designed, delivered over 4 mo., initial visit and assessment, clinic visits every 2 wk., daily telephone calls (providing medical care, teaching, clarification and support), and one group session CG - Standard care | Multidisciplinary team (IG); NR (CG) 4 mo. 4 mo. | HbA1c - No significant differences
Boardway^8^ 1993 | 31 RCT (parallel) Outpatient clinic | IG - Group sessions over 6 mo., 3 phases: self-monitoring, stress-management, regimen adherence CG - Standard care | NR 3 mo. 6 mo. (IG); NR (CG) | HbA1c - No significant treatment effects Self-management/adherence - No significant treatment effects Psychosocial (stress) - Significant decrease in IG at 12 mo. (p<0.05) Coping - No significant treatment effects
Brown^9^ 1997 | 59 RCT (parallel) Home | IG - For 6 mo., children played the video game Packy & Marlon, features characters with diabetes that must engage in self-care CG - For 6 mo., children played a pinball video game with no health-related content | Research staff 6 mo. Immediate | HbA1c - No significant treatment effect (p = 0.67) Health care utilization - IG reported fewer urgent physician visits compared to CG in 3 mo. (p = 0.08, n.s.) Knowledge - IG reported gains in knowledge compared to CG at 6 mo. (p = 0.64, n.s.) Psychosocial (family/social relationships) - IG reported gains in communication compared to CG at 6 mo. (p = 0.025) Psychosocial (self-efficacy) - IG reported gains in self-efficacy compared to CG at 6 mo. (p = 0.07, n.s.) Psychosocial (self-efficacy) - IG reported gains in self-care compared to CG at 6 mo. (p = 0.003)
Campaigne^10^ 1985 | 16 RCT (parallel) NR | IG - 3 45-min. exercise sessions for 12 wk., warm-up and stretching, aerobic movements to music and cool-down CG - Subjects continued with their usual exercise routine | Supervised by principal investigator (IG); NA (CG) 12 wk. Immediate | HbA1c - No change reported in either group at 3 mo. Short-term complications (hypoglycemia) - No increase in occurrence in either group at 3 mo.
Caravalho^11^ 2000 | 56 Uncontrolled before-and-after study Home, diabetes center | IG - Children and parents seen in diabetes team clinic, parents taught insulin adjustment procedures, interventions developed and implemented according to child's age, telephone calls assessed families and assisted in improving self-management, daily calls for newly diagnosed children | Nurse, social worker, dietitian 1 yr. Immediate | HbA1c - Small improvement from pre to post (12 mo.) was not statistically significant (p = 0.73) Psychosocial (self-efficacy) - Higher self-efficacy score pre to post (12 mo.) significant (p = 0.01) Quality of life - Improved mean scores pre to post (12 mo.) not significant (p = 0.07)
Christensen^12^ 2000 | 68 Uncontrolled before-and-after study Camp | IG - 45-min. sessions during 2-wk. camp, 12–18 children per class, grouped by age, carbohydrate counting, label reading, food proportioning and adjusting for activity level, teaching methods tailored to developmental needs | Camp counsellor, physician, nurse 2 wk. Immediate | Knowledge - Correlation not statistically significant (p = 0.09) Self-management skills (write out meal plan in specified formats) - 24% increase comparing pre to post intervention values Self-management skills (accurately describe meal plan) - 19% increase comparing pre to post intervention values Self-management skills (appropriate portion sizes) - Correlation not statistically significant (p = 0.132) Self-management skills (correctly measuring carb.) - Statistically significant correlation (p = 0.006)
Cigrang^13^ 1991 | 37 RCT (parallel) Hospital | IG1 - 8 90-min. group sessions focused on identifying issues perceived as difficult or stressful and developing adaptive strategies for coping, youths asked to implement new coping strategies in real-life situations during the week IG2 - 8 90-min. group sessions with a speaker who presented diabetic topics, included a question and answer session and practice time for various skills CG - Standard care | Diabetes nurse specialist, advanced clinical psychology doctoral student (IG1); diabetes educator, dietitian, endocrinologist, diabetes resource nurse, exercise physiologist (IG2); physician (CG) 8 wk. 3 mo. | HbA1c - IG and CG levels decreased, but not significant (p = 0.43) Coping - No significant differences between groups at 3 mo. (p = 0.122) Psychosocial (self-perception) - No significant difference between groups at 3 mo. (p = 0.493) Psychosocial (depression) - No significant differences between groups at 3 mo. (p = 0.197)
Couper^14^ 1999 | 69 CCT Hospital, home | IG - Standard care, plus 6 monthly home visits for 45–60 min. and weekly telephone contact for 5–10 min. to educate and support adolescents in setting goals for insulin adjustment, BGSM, and target blood glucose range, parents not formally involved in home visits, 24-hour phone access for acute problems CG - Standard care, plus 24-hour phone access for acute problems | Nurse educator (IG); pedatric endocrinologist, diabetes educator, dietitian (IG and CG) 6 mo. 12 mo. | HbA1c - IG significantly lower than CG at 6 mo. (p = 0.0001), no significant difference between groups at 12 mo. Knowledge (child) - IG significantly higher than CG at 6 mo. (p = 0.001), no sig. diff. at 12 mo. Knowledge (parent) - IG significantly higher than CG at 6 mo. (p = 0.001) and 12 mo. (p = 0.005)
Coupland^15^ 1992 | 32 RCT (parallel) NR | IG - 3–5 sessions over 2–2.5 mo. Attended by parents, patient, and siblings closest in age to patient, 1 diabetes skills review and update session, 2–4 family adherence counseling sessions CG - 3–5 sessions over 2–2.5 mo., 1 diabetes skills review (1 parent and patient) and update session, 2–4 stress coping strategy sessions (patient only) | Ph.D. candidate (IG); diabetes educator (IG and CG) 2.5 mo. 3.5 mo. | HbA1c - No significant difference between groups at 6 mo., both groups improved Self-management/adherence - IG significantly different compared to CG at 6 mo. (p<0.05) Self-management/adherence (mean freq. of BG testing) - IG significantly increased compared to CG at 6 mo. (p<0.001) Self-management/adherence (mean percent of BG testing) - IG significantly higher than CG at 3 and 6 mo. (p<0.0005) Psychosocial (family/social support) - No significant difference between groups at 6 mo.
Delamater^16^ 1991 | 13 RCT (parallel) Hospital outpatient clinic | IG - Six 90-min. group sessions held over 2 mo. With a booster session 4 wk. after the last session, self-management and psychosocial skills, separate parent and teen discussions CG - Standard care | Multidisciplinary team (IG); NR (CG) 2 mo., plus 1 booster session 4wk. later (IG); NA (CG) 4 mo. | HbA1c - No significant changes between groups at 4 mo. Self-management/adherence - IG rated themselves as adhering more than CG at 4 mo. (p<0.09) Psychosocial (diabetes specific patient-report) - No significant effects between groups at 4 mo. (p>0.05) Psychosocial (diabetes specific parent-report) - No significant effects between groups at 4 mo. (p>0.05) Psychosocial (general patient report) - No significant effects between groups at 4 mo. (p>0.05) Psychosocial (general parent report) - No significant effects between groups at 4 mo. (p>0.05) Psychosocial (diabetes-specific non-supportive parent behaviors, patient self-report) - No significant effects between groups at 4 mo. (p>0.05) Psychosocial (diabetes-specific non-supportive parent behaviors, parent self-report) - No significant effects between groups at 4 mo. (p>0.05) Psychosocial (diabetes-specific supportive parent behaviors, patient self-report) - No significant effects between groups at 4 mo. (p>0.05) Psychosocial (diabetes-specific supportive parent behaviors, parent self-report) - No significant effects between groups at 4 mo. (p>0.05)
Delamater^17^ 1990 | 36 RCT (parallel) Hospital, home | IG1 - 7 sessions held in the 4 mo. After discharge, additional sessions at 6 and 12 mo., SMBG, self-management skills aimed at developing and reinforcing problem solving strategies IG2 - 7 sessions held in the 4 mo. After discharge, additional sessions at 6 and 12 mo. Focused on psychosocial adjustment issues, patients encouraged to keep accurate BMBG records CG - Standard care | Social worker with diabetes expertise (IG1); social worker (IG2); physician, dietitian (CG) 12 mo. 12 mo. | HbA1c - Self-management training significantly lower than CG at 2 yr. (p<0.05)
Dougherty^18^ 1999 | 63 RCT (parallel) Hospital, home | IG - Home visits 1–2 times a day for the first 2–3 days, instruction and supervision of treatment, problem solving encouraged during followup, diabetologist and dietitian teaching offered 2 wk. after diagnosis, patient hospitalized if necessary CG - Patient hospitalized for metabolic stabilization, initial insulin therapy, and teaching sessions provided | Multidisciplinary team 2 wk. 36 mo. | HbA1c - Home-based group had significantly lower values compared to hospital group at 24–36 mo. (p<0.02) Short-term complications (adverse events) - No significant differences between groups Short-term complications (chronic hyperglycemia) - No significant differences between groups Short-term complications (DKA) - No significant differences between groups Short-term complications (hyperglycemia and ketosis) - No significant differences between groups Short-term complications (severe hypoglycemia) - No significant differences between groups Knowledge - No significant differences between groups Self-management/adherence - No significant differences between groups Psychosocial (stress) - Hospital group significantly lower at 1 mo. Compared to home-based group (p<0.05) Coping - No significant differences between groups School Performance - 28.3±36.4 days of absence for the CG and 29.7±28.7 days for the IG
Golden^19^ 1985 | 19 CCT Diabetes center, parent care unit, a motel-like setting | IG - Teaching occurred in a motel-like setting where entire family stayed and was responsible for care, learned diabetes management skills and dietary guidelines, initial crisis intervention offered to families, psychosocial support occurred at 3-mo. Intervals preceded by a 1-hr session with 5–6 other families CG - Delayed treatment, intervention began an average of 14.9 mo. After initial treatment group | Psychiatric social worker (IG and CG) NR 6–24 mo. (at least partially concurrent with treatment) | HbA1c - Overall CG mean HbA1c > IG mean HbA1c (p<0.10), at equivalent durations of illness Health care utilization - IG - 1 hospitalization after diagnosis and education, CG - 11 hospitalizations before intervention Short-term complications (hypoglycemia) - Significant decrease in CG children and IG relative to both groups (p<0.01)
Greco^20^ 2001 | 23 Uncontrolled before-and-after study Outpatient clinic | IG - Four 2-hr sessions, composed of 3–6 pairs (diabetes patient and peer), reviewed homework, focused on etiology, physiology and treatment of diabetes, reflective listening skills, problem solving related to diabetes, stress management, game or exercise to practice concepts and homework assignment | Psychologist 4 wk. Immediate | Knowledge - At post-intervention, adolescents with DM experienced significant increase (p<0.0001) as did their peers (p<0.0001) compared to baseline Self-management/adherence - No significant change reported Psychosocial (family/social support) - Peers provided greater proportion of support relative to family members following intervention (p<0.05) Psychosocial (family/social relationships) - Parents reported significantly less DM-related conflict following intervention (p<0.05) Psychosocial (peer interaction record) - Peers reported significant improvement following intervention (p<0.01), adolescents reported no significant change Pyschosocial (behavior, affective, and attitudinal adjustment to type 1 DM) - Trend towards improved adjustment, though not significant Psychosocial (social, academic, job, behavior, athletic competence) -No significant change reported
Grey^21^ 2000 | 77 RCT (parallel) Hospital, home | IG - Standard care, plus 6 weekly coping skills training sessions, retrained inappropriate or nonconstructive coping styles, modeled appropriate behaviors, emphasis on social problem solving, skills training, cognitive behavior modification and conflict resolution CG - Standard care, monthly outpatient visits, plus interim telephone contact | Multidisciplinary team (IG and CG) 4 to 8 wk. 12 mo. | HbA1c - IG subjects had significantly lower HbA1c than CG (p = 0.001) after 12 mo. Short-term complications (severe hypoglycemia, male) - 48 episodes, 27 in IG, 21 in CG (p = 0.24) Short-term complications (severe hypoglycemia, female) - 40 episodes, 18 in IG, 22 in CG (p = 0.03) Short-term complications (DKA) - 1 episode (male, IG), (p = 0.16) Pyschosocial (self-efficacy) - IG significantly better self-efficacy (p = 0.002) after 12 mo. Of, both groups statistically significant at 12 mo. Pyschosocial (self-efficacy) - IG significantly better medical self-efficacy (p = 0.04) after 12 mo. Both groups statistically significant at 6 mo. Quality of life - IG experienced less negative (p = 0.005) after 10 mo. Coping - IG less upset about coping with diabetes Coping - IG less hard to cope with diabetes
Gross^22^ 1985 | 14 RCT (parallel) NR | IG - 8 weekly 90-min. sessions, separate parent and child groups, children read and completed 1–2 lessons a week from a text on behavior modification, parents discussed similar topics and were required to conduct a behavior modification project on self-identified, problematic components of their child's diabetes CG - 8 weekly 90-min. sessions, separate parent and child groups, children participated in open ended discussion, parents discussed problems with having a diabetic child | Psychologist (IG and CG) 8 wk. 6 mo. | HbA1c - Significant decrease in HbA1c (both groups) (p<0.01), no significant difference between groups (p>0.05) Knowledge - IG scored significantly higher compared to CG (p<0.01) Self-management/adherence - IG demonstrated an increase in compliance Psychosocial (family/social relationships) - IG dropped from 1.6 conflicts/week to 0.1/week at 2 and 6 mo., CG remained at 1.1 conflicts/week for the entire study period
Gross^23^ 1983 | 11 RCT (parallel) Treatment room | IG - Two 45-min. social training sessions per week for 5 wk., modeling behaviors, providing feedback and praise, trained on one behavior until reliably performed CG - No intervention | NR 5 wk. 6 wk. | HbA1c - No significant difference (p>0.05) (both groups) Pyschosocial (social skills) - percentage eye contact increased from 53–95% (IG) Psychosocial (social skills) - percentage of appropriate verbalization increased from 24–79% (IG) Psychosocial (social skills) - speech duration increased from 1.7–6 seconds Psychosocial (social skills) - affect ratings increased from 1.5–4
Hackett^24^ 1989 | 119 RCT (parallel) Clinic | IG1 - 4 90-min. education sessions over 8 mo., background and management information, insulin, diet and practical problems, 4 90-min. reinforcement session over 8 mo. (following the first session) IG2 - 4 90-min. education sessions over 8 mo. IG3 - 4 90-min. education sessions over 8 mo. Starting 10 mo. After IG1 and IG2 CG - No intervention | Research staff (IG) NA (CG) 16 mo. (IG1); 8 mo. (IG2 and IG3) Immediate (all IG); 16 mo. (CG) | HbA1c - No effect for children <11 yr., marginal improvements for children >11 yr. Knowledge - Increased mean knowledge scores (p<0.001) (all cohorts) Knowledge - Mean scores still raised for mothers and children (p<0.001), no evidence of this for fathers (p>0.05) Knowledge (nutritional management) - No significant difference for children (all ages)
Hains^25^ 2000 | 15 RCT (parallel) Hospital | IG - 3-phase cognitive behavioral stress inoculation training program, 6 1-hr. sessions: conceptualization phase (1 session), skill acquisition and rehearsal phase (sessions 2–4) and application phase (sessions 5 and 6) CG - No intervention | Pyschologist, doctoral student in counseling psychology (IG) 6 wk. 1 mo. | HbA1c - No difference between groups Psychosocial (anxiety) - No difference between groups Psychosocial (stress) - No difference between groups Coping (negative) - No difference between groups Coping (positive) - No difference between groups Coping (behavioral) - No difference between groups
Hakimi^26^ 1998 | 35 RCT (parallel) NR | IG - Same as CG, plus additional 2-hr. program, common emotional/behavioral problems, parental reaction to diabetes diagnosis, common sibling problems, mistakes or misconceptions of outsiders, treatment of diabetic child and family interaction to promote positive adaptation CG - Standard care, 3–4 d. education program | Psychologist (IG); physician, nurse, dietitian (CG) 3–4 d. 6 wk. | Psychosocial (stress) - No significant differences between IG and CG at post-intervention or 6-wk.
Harkavy^27^ 1983 | 93 Uncontrolled before-and-after study Camp | IG - 2-wk. camp, informal and formal teaching sessions, diabetes etiology/pathology, self-management skills, effects of diabetes on stress and social issues | Physician, nurse, camp counsellor 2 wk. Immediate | Knowledge - Significant improvement for 12–13 and 14–15-yr. olds (p<0.01 for each). No significant difference in 10–11-yr. olds over the 2-wk. camp period Self-management skills (urine testing) - Girls performed more accurately than boys, though both sexes improved. Significant improvement for 12–13 and 14–15-yr. olds (p<0.01 for each), no significant difference in 10–11-yr. olds Self-management skills (insulin injection) - Girls performed more accurately than boys (p<0.001), girls improved their accuracy during 2-wk. camp (p<0.01) Knowledge (problem solving) - Significant improvement for 12–13 and 14–15-yr. olds (p<0.01 for each). No significant difference in 10–11-yr. olds over the 2-wk. camp period
Harris^28^ 2005 | 18 Uncontrolled before-and-after study Home | IG - 10 90-min. behavioral family systems therapy sessions, 6–8 weeks covering 4 topics: problem solving, communications skills, cognitive restructuring and functional/structural family therapy | Social worker, psychologist 5–8 wk. 6 mo. | HbA1c - No significant difference in metabolic control at 6 mo. Adherence - No statistically significant differences between baseline and mean 6 mo. Values Coping - No statistically significant differences between baseline and mean 6 mo. Values Self-management/adherence - No statistically significant differences between baseline and mean 6 mo. Values Pyschosocial (family/social relationships) - No statistically significant differences between baseline and mean 6 mo. Values Pyschosocial (diabetes support) - No statistically significant differences between baseline and mean 6 mo. Values Psychosocial (diabetes non-support) - No statistically significant differences between baseline and mean 6 mo. Values
Hill^29^ 2006 | 134 Prospective cohort with concurrent controls Camp | IG - Foundation for Children and Youth with Diabetes 6-day teen camp, knowledge of diabetes management, encouragement to self-monitor and regulate, participated in leisure activities, fostered choice, a sense of self-control and a sense of belonging, on last day campers gathered in small cabin groups to discuss knowledge, questions and comments about camp CG - Camp Hodia, regular camp session | Physician, nurse, dietitian, counselor, assistant (IG); camp counselor (CG) 6 d. 3 mo. | Psychosocial (self-efficacy, competence) - No significant differences between groups Psychosocial (self-efficacy, degree of autonomy) - Greater increase in autonomy in CG versus IG (p = 0,015) Psychosocial (family/social relationships) - IG results significantly higher than for CG (p = 0.03) post-intervention
Hoff^30^ 2005 | 46 RCT (parallel) Hospital, endocrinology clinic | IG - Standard care, plus 2 weekend sessions, 2.5 hr. long, construct of illness (session 1) and uncertainty management techniques (session 2) CG - Standard care | Advanced clinical psychology graduate students (IG); NR (CG) Two 2.5 hr. sessions 6 mo. | Psychosocial (depression, maternal report of child internalizing problems) - IG had significantly decreased internalizing behavior at post-int. and 6-mo. Compared to baseline (p = 0.01 and 0.02, respectively) Psychosocial (depression, paternal report of child internalizing problems) - CG had significantly decreased internalizing behavior at post-int. compared to baseline (p = 0.001) Psychosocial (maternal report of child externalizing problems) - IG had significantly decreased externalizing behavior at post-int. compared to baseline (p = 0.01) Psychosocial (paternal report of child externalizing problems) - No significant changes for either group when compared to baseline
Horan^31^ 1990 | 20 RCT (parallel) Home | IG - 7 weeks of diabetes education modules (phase 2), dynamic and colorful, subjects determined when and what modules to read, recorded insulin and blood glucose data daily on computer and mailed data to investigators every 3 wk., 8 wk. of goal setting and problem solving modules (phase 3), subjects focused on self-control and applying information from education sessions CG - 7 wk. diabetes education, modules were static and black-and-white, subjects determined when and what modules to read, recorded insulin and blood glucose data and mailed to investigators every 2 wk., 8 wk. of goal setting and problem solving, no additional modules | Commodore computer (IG); printed materials (CG) 15 wk. Immediate | HbA1c - No significant changes between groups Knowledge (diabetes, applied) - No significant differences between groups at posttest Knowledge (diabetes, factual) - More IG subjects showed improvement compared to CG (no stats) Self-management/adherence - IG reported more behavioral change as function of what was learned (no stats)
Howe^32^ 2005 | 75 RCT (parallel) Diabetes center (all); home (IG2) | IG1 - Standard care, plus 1 education session with families, basic diabetes management skills, families given customized written guidelines, parents expected to identify problems and know when to call for assistance IG2 - Standard care, plus IG1, plus telephone calls from study coordinator, standardized protocol, diabetes management techniques, parental and behavioral management skills discussed with parent CG - Standard care | Master's-prepared nurse (IG1, IG2 and CG), pediatric endocrinologist (IG1 and IG2); study coordinator (IG2) 6 mo. Immediate | HbA1c - No significant differences between groups at 3 or 6 mo. Knowledge - No statistically significant differences were found from baseline-6 mo. Among groups Psychosocial (assume age-appropriate behaviors) - Positive significant group × time interaction (p = 0.002), ED+ group significant increase compared to CG (p = 0.0003) Psychosocial (diabetes safety/control behaviors) - Positive significant group × time interaction (p = 0.0006), ED+ group significant increase compared to CG (p = 0.0002)
Kaplan^33^ 1985 | 21 RCT (parallel) Summer school | IG - 5 social skills training sessions, 3 hr. a day over 1 wk., identified social situations where peer influence might cause variation in diabetes regimen and suggested appropriate responses CG - 5 diabetes knowledge lectures and small group discussion, 3 hr. a day over 1 wk., an interactive computer system, educational videos and an assignment identifying important facts for diabetic teens | Pedatric endocrinologist, expert in diabetes care (IG and CG); psychology graduate student (IG) 3 wk. 4 mo. | HbA1c - IG had significantly lower levels at 4 mo. (p<0.05)
Karaguzel^34^ 2005 | 25 Uncontrolled before-and-after study Camp | IG - 1-wk. camp, education in the morning, during meals and spontaneously, self-management skills, recognition of hypoglycemia, DKA, adjustment related to nutrition and activity level, complications, importance of control and new therapies | Multidisciplinary team 1 wk. 12 mo. | HbA1c - Post-camp values at 6 and 12 mo. Significantly decreased (p<0.05) Short-term complications (hypoglycemia) - No significant difference at 6 mo. (p>0.05 vs. 3 and 12 mo. Values) or 12 mo. (p>0.05 vs. 3 and 6 mo. Values) Knowledge - Significant increase post-camp and 6 mo. (p<0.05 vs. pre-camp and 3 mo. Values) and 12 mo. (p<0.01 vs. pre-camp)
Kemp^35^ 1986 | 42 Uncontrolled before-and-after study Camp | IG - 2-wk. camp, 8 hr. of formal diabetes education either as lectures or computer assisted instruction; eye, skin and foot care, treatment of hypo- and hyperglycemia, nutrition, insulin adjustment and exercise | NR 2 wk. 1 yr. | HbA1c - No significant long-term change Knowledge - Improvement in knowledge scores comparing pre to post intervention were significant (p<0.0001)
Kennedy-Iwai^36^ 1991 | 19 RCT (parallel) Home (IG); hospital (CG) | IG - Standard care, plus 6–8 sessions of a couple communication program using the text Couple Communication 1: Talking Together, explored feelings and intentions, active listening, observing and information checking, communication styles and providing support, program delivered at home CG - Standard care, plus education on self-management skills, could also receive information on stress management, child-rearing and handling emotions surrounding diagnosis | Research staff, counseling psychologist (IG); NR (CG) 8–10 hr. (IG), NR (CG) 3 mo. (IG), NR (CG) | HbA1c - Levels increased from pre to posttest in both groups Psychosocial (family environment, cohesion) - Scores returned to pretest values at 3 mo. Psychosocial (family environment, conflict) - IG mothers had lower scores than CG mothers at posttest; no differences for fathers, at 3 mo. Treatment gains disappeared
Koontz^37^ 2001 | 112 Uncontrolled before-and-after study Camp | IG1 (grades 9–10) - 1-wk. camp, self-management skills, insulin administration, the relationship between diet, exercise and insulin, meal and snack planning, selecting and measuring food portions, SMBG, identifying and treating insulin reactions, aimed to enhance camper's emotional adjustment and improve self-esteem IG2 (grades 6–8) - same as IG1 IG3 (grades 2–5) - same as IG1 | Camp counsellor 1 wk. 3 mo. | HbA1c - Not extracted as high losses to followup Health care utilization - No hospitalizations in 29 who completed medical followup form Health care utilization - 3 campers visited physician for other than regular check-up Self-management skills - No significant difference between pre and post camp but older campers better than younger campers, though younger competence increased over time Psychosocial (self-perception) - Differences at 3 mo. In perceived athletic competence Coping - Campers differed in their coping strategies as a function of age
Laffel^38^ 2003 | 105 RCT (parallel) Diabetes center (both); home (CG) | IG - Written material and family discussion on 4 module topics: communication, meaning of HbA1c and need for teamwork during adolescent period, response to blood sugar tests and sharing the burden of diabetes tasks, at the end of each session a responsibility-sharing plan was negotiated CG - Standard care, plus written material from IG at the end of the study | Research staff 1 yr. Immediate | HbA1c - IG reported significantly lower levels (p<0.05) at 12 mo. Psychosocial (roles/responsibilities) - IG had significantly more involvement than CG (p = 0.05) at 12 mo. Psychosocial (diabetes-related conflict, patient self-report) - No significant differences between groups at 12 mo. Psychosocial (diabetes-related conflict, parent self-report) - No significant differences between groups at 12 mo. Quality of life - No significant differences between groups at 12 mo.
Lawson^39^ 2000 | 28 Retrospective cohort Diabetes center (both); home (IG) | IG - 6–8 hr of education (comparable to the DCCT), over 3–4 sessions on an outpatient basis, weekly phone contact reviewed insulin dose adjustments and provided ongoing support, diabetes clinic visits CG - Two 2-hr. group education sessions attended by patient and their parents, one 1–2 hr individualized session, meal plans and insulin dose adjustment, small group problem solving sessions, weekly physician contact encouraged | Nurse, dietitian (IG and CG); research fellow (IG); diabetologist (CG) 3 mo. 12 mo. | HbA1c - Both groups had a significant decrease in levels at 3 mo.; over the following 12 mo. Levels increased in both groups; IG mean HbA1c remained significantly lower than baseline levels (p = 0.001), CG mean HbA1c did not differ significantly from baseline Short-term complications (hypoglycemia) - 2 patients in IG group had severe hypoglycemic reactions at 12 mo.
Likitmaskul^40^ 2002 | 52 Cohort with historical comparison Hospital (IG); NR (CG) | IG - Hospital admission, 10–12 d., or until family felt comfortable, patient and at least 1 family member attended program, self-management skills, how to manage abnormal blood and urine sugar levels and how to detect and correct hypoglycemia, followup visits to education clinic once a month for 3 mo., then every 3 mo. Thereafter CG - Standard care (historical control) | Multidisciplinary team (IG); NA (CG) 10–12 days (IG); NR (CG) Average follow up: 43.5 ±13.1 mo. (IG); 39.9 ±26.8mo. (CG) | HbA1c - IG had lower HbA1c levels than CG Health care utilization - Average length of first admission in IG was much shorter than CG Health care utilization - Readmission rate for CG was 10 times more than IG in second yr.
Lipman^41^ 1988 | 30 Retrospective cohort Hospital | IG - Group instruction coordinated and education provided by a clinical nurse specialist with help from staff nurses, daily education plan delineated responsibilities, diabetes care plan revised and expanded to include child/family assessment tool, reading material and discharge criteria same as CG CG - Staff nurses provided instruction according to diabetes education flowsheet and standardized diabetes care plan, education booklet provided, tasks depended upon age, discharged when child and/or parent could perform diabetes tasks and answer questions | Nurse (both); clinical nurse specialist (IG) NR None | Health care utilization - IG had significantly shorter length of hospitalization than CG (p<0.01)
Lucey^42^ 1985 | 49 CCT NR | IG - Two 6-hr. small group sessions using demonstration, drama and a video camera, video facilitated discussion, problem solving alternatives discussed, a canteen-style lunch provided and video taken of food choices used for nutrition discussion, second session provided evening tea and observation of insulin injection CG - No intervention | Layperson, adult leader (IG); N/A (CG) Two 6-hr. sessions 4–22 wk. | Knowledge - IG children performed better on general information questions than CG children (p<0.05) Pyschosocial (problem solving) - Difference between IG and CG on problem solving questions not statistically significant
Mann^43^ 1984 | 39 RCT (parallel) Home, outpatient clinic | IG1 - Teaching during home visits, injection sites inspected, videos on procedures available in waiting area of clinic, group discussion or practical dietary demonstrations, telephone contact encouraged to discuss problems in diabetes management, glucose measurements recorded IG2 - Same as IG1, plus glucose measurements recorded graphically, patients given dose-regulation algorithms, attempted to achieve specified glucose levels | Physician, diabetes educator, dietitian NR 18 mo. | HbA1c - A1c levels had seasonal fluctuation, but values at beginning and end of study were nearly identical in both groups Health care utilization - SMBG group showed reduction in number of hospitalizations for stabilization of control and ketoacidosis (p<0.04)
Marteau^44^ 1987 | 97 Uncontrolled before-and-after study Hotel | IG - Weekend program, parents divided into groups, sessions on problem solving, forming self-help groups, health care for diabetics, ways to achieve best care | Multidisciplinary team 1.5 d. 3 mo. | Coping - Perceived difficulty of looking after child remained unchanged at 3 mo. Coping - Parents rated themselves significantly more confident in looking after their child post treatment and at 3 mo.
Mason^45^ 1985 | 93 CCT School, diabetes center | IG - 2–4 player board game designed to support the role of the health care team, alert individuals to possible complications of diabetes, provide opportunities for discussion and decision making and the ability to control diabetes, players collected tools (cards) for management to ensure continued control, player with the most tools wins | Diabetes educator NR NR | Knowledge - Both CG and IG significantly improved knowledge scores from baseline, but there was no significant difference between the two groups
Massouh^46^ 1989 | 33 RCT (parallel) Camp | IG - 1-hr. program presented on self-management and the physiology of diabetes, 40-min. social learning intervention session, role modeling used to enact behaviors used to deal with peer pressure CG - 1-hr. program presented on self-management and the physiology of diabetes, 40-min. session developing questions for a game show | Diabetes expert (IG and CG); psychologist (IG) 8 d. 3 ½ mo. | HbA1c - No significant differences between IG and CG at 3 mo., paired t-test states significant increase in HbA1c after Tx in the IG
McNabb^47^ 1994 | 24 RCT (parallel) Diabetes center | IG - 6 1-hr sessions, children learned and practiced relevant self-care behaviors, parents learned parenting skills, at the end of the session children set self-care goals and practiced the behaviour with their parents, modified goal to a less demanding one if necessary CG - Standard care | NR (IG); Physician, nurse, dietitian (CG) 6 wk. (IG); 0 wk. (CG) 6 wk. (IG); 12 wk. (CG) | HbA1c - Mean HbA1c was significantly lower in IG than CG (p<0.04) but not significant so when compared to baseline levels Self-management/adherence - Difference between IG and CG was not statistically significant Pyschosocial (family/social support) - Children in IG had mean overall responsibility score that was significantly higher than children in CG
Mendez^48^ 1997 | 37 CCT Health center (IC); NR (CG) | IG - 12 sessions, review, new content (audiovisual and printed material), skill practice and homework assignment, parents attended 2 sessions, emphasizing reinforcement of adherence behaviors rather than punishing noncompliance CG - NR | The authors of the paper, psychologist (IG); NR (CG) January–April 1993 13 mo. | Knowledge - IG significantly higher than CG at posttest (p = 0.000) but not sig. diff. at 13 mo. (p = 0.087) Knowledge (self-management, nutritional management, physical activity) - IG significantly higher than CG at posttest (p = 0.016), but loses significance at 13 mo. Self-management skills - IG significantly higher than CG at posttest (p = 0.002) Pyschosocial (roles/responsibilities) - No significant differences between groups for positive or negative family support at posttest or 13 mo. Coping (specific daily diabetes-related hassles) - IG significantly lower than CG at posttest (p = 0.000) and at 13 mo. (p = 0.006) Coping (degree unease and likelihood of response relating to diabetes) - IG significantly lower than CG at posttest (p = 0.040) and at 13 mo. (p = 0.000)
Mitchell^49^ 1996 | 32 RCT (parallel) Diabetes center | IG - Standard care, plus booklet Improving Compliance with Treatment for Diabetes, identifies problems with adherence and offers basic self-management skills, contents reviewed with patient CG - Standard care | Multidisciplinary team (IG and CG) NR 12 mo. | HbA1c - IG significantly lower compared to CG (p<0.01) at 10–13 mo. Pyschosocial (depression) - No significant differences between groups. IG significant comparing 1–3 mo. (p<0.05) and 3–12 mo. (p<0.01) Psychosocial (family/social relationships) - No significant differences between groups, IG significant comparing 1–12 mo. (p<0.05) Coping (perceived difficulties, diabetes management) - No significant differences between groups Coping (social function, general adjustment) - No significant differences between groups
Monaco^50^ 1996 | 58 Uncontrolled before-and-after study Diabetes center | IG - 1 session, children instructed in the use of injection site charts (before) and injection site bears (after) | Research staff Single event Immediate | Knowledge (6–8 yr. olds) - Using the bear there were significantly fewer injection site identification errors compared to using the chart (p = 0.0005) Knowledge (9–11yr. olds) - Using the bear there were significantly fewer injection site identification errors compared to using the chart (p = 0.0001)
Moran^51^ 1991 | 22 CCT Hospital, home | IG - 45-minute psychotherapy sessions, probable cause of child's psychological disturbance determined during initial meeting, interviews unstructured and focused on child's interest and emotional concerns CG - Standard care, possible therapy for emotional problems | Psychologist, nurse 45-minute sessions 3–5 meetings/week for 5–28 weeks (IG); 1–12 weeks (CG) 12 mo. | HbA1c - IG had significant improvement at 12 mo. (14.3 vs. 11.5 percent), CG no change (13.7 vs. 13.5 percent) Health care utilization - At 12 mo. No significant difference in overall hospitalizations, IG had significantly fewer diabetes-related hospitalizations than CG
Nordfeldt^52^ 2005 | 332 RCT (parallel) Home | IG1 - 2 video programs (17 and 18 min.) received at baseline, reviewed practical self-management skills aimed at preventing hypoglycemia, FAQ brochure (32 pp., 5,200 words), received 1 mo. Later, information on symptoms and prevention of hypog;ycemia and maintenance of normoglycemia IG2 - Standard care, plus video (13-min.) and brochure (16 pp., 800 words) with general diabetes information CG - Standard care | Videotape, brochure (IG and IG2), NA (CG) NA (expected to use tools as needed) 24 mo. | Short-term complications (hypoglycemic events) - Significant reduction after 24 mo. In IG (p = 0.0241), no such reduction in either of other two groups
Nordfeldt^53^ 2002 | 130 Prospective cohort with historical controls Home | IG - 2 self-study brochures, prevention of severe hypoglycemia (16 pp., 1,800 words) and self-management skills (12 pp., 1,500 words), 2 video programs (17 and 18 min.) with content related to brochures mailed later, outpatient clinic visits | Videotape, brochure NA 3 yr. | HbA1c - Significant decrease from 1996–7 (p = 0.042) and from 1996–8 (p = 0.006) Short-term complications (severe hypoglycemia with unconsciousness events/pt. yr.) - Both groups decreased, but difference was not significant Short-term complications (yearly percent patient hypoglycemia with unconsciousness) - Both groups decrease, but difference was not significant
Nordfeldt^54^ 1999 | 139 Prospective cohort with historical controls Home, community, school, diabetes center | IG - Scheduled visits to individual families, intense problem-based training, supplemented by training at camps and evening lectures, continuous individual psychosocial support provided | Multidisciplinary team Median: 4 visits/yr. (range 3–8) 248 patient yr. | HbA1c - Mean HbA1c in 1994–5 different from 1980–1 (p = 0.004) Health care utilization - Decrease from 3 incidents in 2 patients in 1994 to 0 incidents in 1995 (significance not calculated) Short-term complications (hypoglycemia) - Decrease from 0.23 events/patient yr. in 1980–81 cohort to 0.17 events/patient. Yr. in 1994 and 1995 Short-term complications (DKA) - No change reported in number of events/pt. yr. for IG
Nunn^55^ 2006 | 123 RCT (parallel) Home (IG) diabetes center (both) | IG - 15–30-min. phone calls, 3 main topics: insulin, carbohydrate intake, and blood glucose values, events which may impact diabetes management, and education program, spoke to parent if child unable to make independent decisions CG - Standard care | Diabetes educator (IG), pediatric endocrinologist (IG and CG) 5–8 mo. Immediate | HbA1c - No significant differences between groups Health care utilization - No significant differences between groups Knowledge - No significant differences between groups Psychosocial (emotional score) - No significant differences between groups Psychosocial (conduct score) - No significant differences between groups Pyschosocial (hyperactive score) - No significant differences between groups Psychosocial (peer problem score) - No significant differences between groups Psychosocial (pro-social score) - No significant differences between groups
Olmsted^56^ 2002 | 85 RCT (parallel) Diabetes center | IG - 6 weekly 90-min. sessions adapted from a standardized intervention for eating disorders, parents and daughters in separate rooms, written and oral presentations on the nature of eating problems, strategies for change, patients asked to read chapters from a manual before each session CG - Standard care | Individuals with expertise in eating disorders, and adolescent diabetes (IG); NR (CG) 6 wk. 6 mo. | HbA1c - No significant differences between groups Psychosocial (binge episodes, past 28 days) - No significant differences between groups, though means suggest most improvement was in IG Pyschosocial (insulin omission, past 28 days) - No significant differences between groups Psychosical (drive for thinness) - Significant time effect for the IG (p<0.00005) compared to CG Psychosocial (bulimia) - No significant differences between groups Psychosocial (body dissatisfaction) - Significant time effect for the IG (p<0.00005) compared to CG
Panagiotopoulos^57^ 2003 | 50 RCT (parallel) Home, diabetes center | IG - 1–2 times per week educator telephoned patients for 15–20 min., recorded blood glucose values and adjusted insulin, encouraged more frequent SMBG and record keeping, reinforced target blood glucose values, educated on insulin adjustment, addressed teen issues and encouraged individualized goal-setting CG - Standard care | NR 6 mo. 12 mo. (continuous) | HbA1c - Significant decreases at 6 mo. In both the CG (p = 0.04) and IG (p = 0.01), but no significant differences between the groups
Pichert^58^ 1994a | 83 RCT (parallel) Camp | IG - 3 45-min. groups sessions devoted to nutrition-related skills and knowledge, written material, video, made food choices for a 3-day high energy adventure CG - 3 45-min. session using flash cards to learn food group/exchange equivalents and meal planning | Diabetes educator (IG); dietitian (IG and CG) 3 45-min. sessions Tested at 2–4 d. and 5–6 d. | Knowledge (recall nutritional meal plans) - Significant improvement in both groups, group × time interaction (p<0.01) Knowledge (food groups, exchange equivalents, portions) - No significant difference between groups Self-management skills (behavioral measures) - No significant difference between groups, though both showed improvement Self-management skills (choosing meals, overnight trip) - No significant difference between groups, though both showed improvement
Pichert^59^ 1994b | 84 RCT (parallel) Camp | IG - 2 45-min. sessions, video and discussion, 9 guidelines for sick-day management CG - 2 45-min. sessions, viewed video, and completed paper and pencil activity (session 1), reviewed knowledge, played games that prompted rehearsal and application of sick-day guidelines, discussion (session 2) | Diabetes educator (IG and CG) 2 45-min. sessions 8 mo. | Knowledge - Older campers outperformed younger (p<0.01) but no significant difference between study groups Knowledge (overall recall) - Older campers outperformed younger (p<0.01) but no significant difference between study groups Knowledge (guideline rationale) - Older campers outperformed younger (p<0.01) but no significant difference between study groups Knowledge (guideline recall) - Older campers outperformed younger (p<0.01) but no significant difference between study groups School performance - No significant difference between study groups
Pichert^60^ 1993 | 70 RCT (parallel) Camp | IG - 4 45-min. sessions during a 2-wk. camp, topics included guidelines for testing glucose and ketons, calculating snacks needed to cover for exercise, preventing dehydration, wearing identification and carrying sugar, all classes were presented according to IDEAL method CG - 4 45-min. sessions during a 2-wk. camp, topics included guidelines for exercise and diabetes, open discussion on social issues and diabetes, IG instructor videotaped sessions for CG, which was then show by a proctor to CG | Nurse, physician, camp counsellor (IG and CG) 4 45-min. sessions Immediate | Knowledge (diabetes-related exercise guidelines) - Older subjects outperformed younger ones (p<0.001), overall posttest scores were higher than pretests (p<0.01), the interaction between group and time of testing was significant (p<0.05) Knowledge (ability to apply knowledge) - Older subjects outperformed young ones (p<0.001), overall posttest scores were higher than pretests (p = 0.08), the interaction between group and time of testing was significant (0.058)
Povlsen^61^ 2005 | 37 Uncontrolled before-and-after study Hospital | IG - 7 re-education sessions, parents and children focused on increasing knowledge, self-care and providing psychosocial support | Nurse Aug 2002–June 2003 6 mo. | HbA1c - Significant decrease after intervention (p = 0.01), but levels increased to no significant difference at 3 and 6 mo. Short-term complications (hypogycemic events) - Total number of events increased but not significantly Short-term complications (DKA) - One event occurred during intervention Knowledge - Mean increase in knowledge but with considerable differences between families
Remley^62^ 1999 | 237 CCT Camp | IG1 - Week long camp, 1-hr. didactic lecture on assertive communication, 1-hour peer group discussion, 1-hr. play, 1-hr. nutritional education CG - Attended camp, no specialized education | Physician, nurse, camp counselor, nutritionist (IG); NA (CG) 1 wk. 3 mo. | HbA1c - No significant change for both groups Knowledge (carb. Counting) - No significant difference from pre to post camp Knowledge (food guide pyramid) - No significant difference from pre to post camp Self-management skills (meal planning self-efficacy) - IG decreased slightly, CG increased slightly from pre to post camp, significant time × group interaction (p<0.01), but not for 2 × 3 general linear model (p = 0.26) Adherence - No significant difference from pre to post camp Pyschosocial (family/social support ) - No significant difference from pre to post camp Psychosocial (family/social support, diabetes) - No significant difference from pre to post camp Psychosical (family/social support, quality) - No significant difference from pre to post camp Psychosocial (self-efficacy) - No significant difference from pre to post camp. IG up slightly from pre to post then decreased at followup, CG down slightly pre-post then increased at (not significant)
Satin^63^ 1989 | 32 RCT (parallel) Hospital | IG1 - 2 90-min. sessions established group process, stressed that diabetes is a family disease and requires teamwork, discussion of feelings around diabetes, 4 90-min. sessions on diabetes management and adherence IG2 - Same as IG1 plus, parents simulated diabetes self-management for 1 week, adolescents taught parents how to manage their diabetes CG - No intervention | Social worker, nurse practitioner (IG1 and IG2); NA (CG) 6 wk. 6 mo. | HbA1c - IG2 improved significantly compared to CG; IG1 showed improvements, but results were not significant Psychosocial (family/social relationships) - No significant changes
Schlundt^64^ 1996 | 86 Uncontrolled before-and-after study Camp | IG - 2 sessions, 1–3 days apart, used a 17-min. video on obstacles faced by adolescents with diabetes, campers identified, analyzed and proposed solutions, then apply them to their own lives | Dietitian 2 wk. Immediate | Psychosocial (total, cognitive and behavioral) - Statistically significant increase in score after intervention (p<0.01) Psychosocial (patient belief in self-care abilities) - No significant change in score after intervention
Shobhana^65^ 1997 | 37 Uncontrolled before-and-after study Diabetes center, hospital | IG - 1 day consisted of 1-hour didactic lecture on diabetes with a question and answer period, injection and monitoring skills, pamphlets and other reading material, individualized diet-counseling | Multidisciplinary team NR (approximately 1 d.) 6 mo. | Knowledge - Significant increases comparing initial testing and 3 mo. For IDDM, insulin, injections, hypoglycemia and total score. Significant increases comparing initial testing and 6 mo. For all knowledge areas except self-monitoring
Siminerio^66^ 1999 | 32 Prospective cohort with concurrent control group Hospital (IG1); home (both); outpatient clinic (IG2) | IG1 - 10–12 hr. of inpatient education sessions over 3 d., individualized, basic knowledge about diabetes, hypo- and hyperglycemia, self-management skills, nutrition and exercise, follow-up telephone calls made IG2 - Same as IG1, except on an outpatient basis | Diabetes educator, dietitian 3–5 d. 1 mo. | Health care utilization - No reported episodes in either group during 1^st^ month post diagnosis Knowledge - No significant differences between groups Knowledge (problem solving) - Outpatients scored significantly higher than inpatients on behavior control (p<0.004) and roles (p<0.04) at 1 mo. Self-management/adherence (BG regulation) - Inpatient group significantly higher than outpatient group (p<0.01) at 1 mo. Self-management/adherence (emergency precautions) - Outpatient group significantly higher than inpatient (p<0.001) at 1 mo. Psychosocial (family/social support) - Increase not significant (p = 0.08) in the outpatient group Coping - No significant differences between groups
Smith^67^ 1993 | 120 Uncontrolled before-and-after study Camp | IG - Daily 1-hr. sessions during a 5-d. camp, provided information, facilitated sharing, opportunities to practice assertive communication, problem solving and negotiation skills, general and diabetes-specific situations discussed, sessions included 7–9 campers | Medical education staff 5 d. 3 mo. | Pyschosocial (self-perception) - Significant increase (p<0.01) comparing beginning of camp to last day of camp Psychosocial (family/social relationships) - No significant changes in degree of problems in communicating, adolescents reported significant decrease in open communication with fathers (p<0.05), and similar n.s. trend with mothers (p<0.06) post camp
Smith^68^ 1991 | 108 Uncontrolled before-and-after study Camp | IG - Daily 1-hr. sessions on stress and diabetes, management techniques described, modeled and practiced using relaxation, imagery, exercise, problem solving and challenging negative thoughts and cognitive distortions | Medical education staff NR NR | Coping - No significant change from pre to postcamp
Srinivasan^69^ 2004 | 110 Prospective cohort with concurrent control group Outpatient day care program (IG); hospital (CG) | IG - Diabetes day care program attended by family for 2–3 successive d. for “survival skills” diabetes education, printed guide and instructions on when to contact on-call team for assistance, additional 3–4 formal education sessions, families attended an outpatient clinic CG - Hospitalized for 4–7 d. for detailed education program, families returned to new-patient clinic within 3–6 wk. | Multidisciplinary team 4–6 wk. (IG); 4–7 d. (CG) 12 mo. | HbA1c - No significant differences between groups Knowledge - No significant differences between groups Psychosocial (diabetes responsibility and conflict) - No significant differences between groups Psychosocial (parent-child conflict) - No significant differences between groups Coping - No significant differences between groups
Sundelin^70^ 1996 | 38 RCT (parallel) Apartment on hospital grounds (IG); hospital (CG) | IG - Families lived in training apartment, all members encouraged to move in for 2 wk., family-orientated crisis therapy, interactions occurred through a variety of day-to-day situations using problems and questions formulated by family, customized management strategies, individualized dietary recommendations, followup according to Swedish standards CG - Child hospitalized with one parent, encouraged to attend informative meetings with medical staff, individualized dietary recommendations, followup according to Swedish standards | Multidisciplinary team (IG); Diabetes educator, dietitian (CG) 2 wk. (IG); 3 wk. (CG) 2 yr. | HbA1c - Statistically significant difference observed only in year 2 due to 3 extreme values in study group. Psychosocial (self-perception) - No statistically significant difference between groups Psychosocial (family/social relationships) (parent perception of child social activity/behavioral disturbances) - No statistically significant difference between groups Pyschosocial (family emotional climate) - No statistically significant difference between groups Pyschosocial (attribution, interest, isolation, chaos, enmeshment) - No statistically significant difference between groups
Svoren^71^ 2003 | 301 RCT (parallel) Diabetes center | IG1 - Care ambassador assigned to assist families in scheduling and monitoring appointments, help with billing and insurance issues and provide outreach after missed or canceled appointments IG2 - Same as IG1, plus eight 15–30 min. psychoeducational modules delivered at quarterly clinic visits, family discussion encouraged, 2–3 pp. of written material given after each visit CG - No intervention | Research staff (IG1 and IG2); NA (CG) 24 mo. 24 mo. | Health care utilization (ED visits) - Significantly reduced rate in the CA+ group compared to the other two groups (p = 0.004) over 24 mo. Health care utilization (hospitalizations) - Significantly reduced rate in the CA+ group compared to the other two groups (p = 0.04) over 24 mo. Short-term complications (hypoglcemic events) - Significantly reduced rate in the CA+ group compared to the other two groups (p = 0.02) over 24 mo.
Szumowski^72^ 1990 | 27 RCT (parallel) Outpatient clinic | IG - Six 60–90-min. meetings over 8 wk., children and parents seen separately, at meetings homework reviewed, lesson presented, children completed activities to facilitate learning, parents engaged in discussion, contact maintained with families via monthly mailings and telephone calls, specific diabetes behaviors targeted, goals set in first meeting CG - Same as IG, without diabetes behavior education or goal-setting | Multidisciplinary team 2 mo. 3 mo. | HbA1c - No significant difference comparing baseline to 3 mo. Short-term complications (hypoglycemia events) - No significant difference comparing baseline to 3 mo. Knowledge (behavioral principles as applied to children) - Significant group × time interaction (p<0.008) for both groups comparing 3 mo. to baseline Knowledge (diabetes, children) - Increase in scores from baseline to 3 mo., but statistical significance not reported Knowledge (diabetes, parents) - Increase in scores from baseline to 3 mo., but statistical significance not reported Pyschosocial (roles/responsibilities) - Significant interaction (p = 0.09) comparing baseline with 3 mo. Pyschosocial (family/social relationships) - No significant difference comparing baseline to 3 mo. Self-management/adherence (physical activity) - No significant difference comparing baseline to 3 mo. Self-management/adherence (nutritional management) - No significant difference comparing baseline to 3 mo.
Templeton^73^ 1988 | 30 Uncontrolled before-and-after study Diabetes center | IG - Adolescents met in groups (5–7 people) for 1 90-min. session, arrived at the clinic fasting, took blood sugar then administered insulin while nurse observed, with dietitian, group converted each person's breakfast into exchanges, blood glucose measured at 30-min. intervals and plotted on a graph, discussion about SMBG | Multidisciplinary team 1 90-min. session Immediate | Knowledge (present knowledge, nutritional concepts) - Percent correct range from 35%–92% (M = 76%; median = 84%), no comment on statistical significance of results Knowledge (knowledge gain, nutritional concepts from session topics) - Percent correct range from 96%–100% (M = 97.6%; median = 96%), no comment on statistical significance of results
Thomas-Dobersen^74^ 1993 | 20 CCT NR | IG - 14 90-min. sessions over 3 mo., adolescents learned self-management skills, importance of diet and exercise and knowledge around hypoglycemia, manuals for both adolescents and adults, parents offered 13 sessions covering strategies to support weight-loss, methods to alter family diet and activity patterns and improve parenting and communication skills CG - Standard care | Psychologist, dietitian, child health associate (IG); NA (CG) 3 mo. 1 yr. | Knowledge - Statistically significant increase in IG (p<0.01) compared to CG at 3 or 15 mo. Pyschosocial (self-perception) - 1 CG subject showed improvement at 15 mo., compared to 4 in IG (significance not stated)
Verrotti^75^ 1993 | 30 Uncontrolled before-and-after study NR | IG - 9 2-hr. education sessions over 15 d., delivered one-to-one using simple language, new sessions evaluated discussion from previous one, self-management skills, hyper- and hypoglycemia, nutrition, diet and exercise, diabetes complications and one session dedicated to mixing insulin, parents attended session on diet | Physician, nurse 15 d. 12 mo. | HbA1c - At 12 mo. followup mean levels ahd decreased significantly (p = 0.019) Short-term complications (hypogycemic events) - Significantly lower number of incidents at 12 mo. Knowledge - Significantly higher scores at 12 mo. compared to baseline
Viner^76^ 2003 | 21 CCT NR | IG - 6 weekly sessions, groups broken down by age, motivational and solution-focused therapy techniques, systematic questions, a narrative approach and cognitive behavioural therapy used, parent group run to facilitated parental support for change CG - No intervention | NR 6 wk. 1 yr. | HbA1c - At 4–6 mo. IG significantly decreased compared to CG (p<0.05), at 7–12 mo. IG decreased compared to CG but not significant (p>0.06) Pyschosocial (social skills) - No significant changes in scores Psychosocial (self-efficacy) - Significant improvement in scores for cases receiving intervention (p = 0.014)
von Sengbusch^77^ 2006 | 107 Uncontrolled before-and-after study Hospital | IG - 5 d. of inpatient education by Mobile Diabetic Teaching Team, children grouped (4–6 people) by age, included knowledge, self-confidence, age appropriate independence and self-management, parents trained in groups, or one-on-one, 1–2 times on insulin, sick days and everyday challenges | Physician, nurse 5 d. 6 mo. | HbA1c - No statistically significant changes after 1 yr. Short-term complications (hypoglycemia) - No statistically significant changes after 1 yr. Health care utilization - Statistically significant reduction (p<0.05) comparing pre and post treatment Knowledge - Statistically significant improvement for children <12 yr. (p<0.01) and children >12 yr. (p<0.05) compared to baseline Quality of life - Statistically significant improvement at both 6 mo. (p<0.05) and 12 mo. (p<0.01) compared to baseline
Vyas^78^ 1988 | 63 Uncontrolled before-and-after study Camp | IG - Camp, 10 d. for children 5–7 yr. and 14 days for children 9–14 yr., similar activities during each camp, children learned self-management and problem solving skills | Camp medical staff, camp leaders 10–14 d. 3 mo. | Self-management skills (self-testing blood/urine) - Statistically significant increase of testing (p = 0.003) comparing before holiday to 3 mo. Self-management skills (independent self-injection) - Statistically significant increase in ability (p = 0.042) comparing before holiday to 3 mo.
Wadham^79^ 2005 | 67 RCT (parallel) Clinic | IG - 4 sessions: food enjoyment with carbohydrate counting, insulin dose adjustment, blood sugar testing and HbA1c, teamwork and communication to support blood glucose and independence, sharing responsibility and letting go CG - No intervention | Nurse, physician, dietitian (IG); NA (CG) 12 mo. Ongoing with intervention | HbA1c - reliminary results indicate no significant difference for either group
Webb^80^ 1999 | 66 RCT (parallel) Outpatient clinic | IG - Presentation on the importance of goal setting, 5 guidelines for goal setting given to parent and child, therapist encouraged child-parent dyads to select 1 goal in 4 self-care behavioral areas, parents worked closely with children, trained to use goal setting worksheets to assist recording and monitoring goal process CG - Child-parent dyads worked with therapist to set goals using goal setting worksheet | Research staff (IG and CG) 12 wk. 3 mo. (IG); 2 mo. (CG) | HbA1c - No significant interaction between groups and assessment phases (all p>0.05) Self-management/adherence (GAS for insulin administration) - Significant increase (p<0.042) in CGS at 3 mo. compared to GSO Self-management/adherence (GAS for SMBG) - No significant differences between groups at 3 mo. Self-management/adherence (GAS for physical activity) - Significant increase (p = 0.011) in CGS at 3 mo. compared to GSO Self-management/adherence (GAS for food intake) - Significant increase (p = 0.001) in CGS at 3 mo. compared to GSO assessment phases (all p>0.05) Self-management - No significant interaction between groups and assessment phases (all p>0.05)
Wolanski^81^ 1996 | 41 RCT (parallel) Camp | IG - Camp, 1–2 individualized 15–30 min. sessions, self-testing under supervision, received corrections, discussed importance of correct testing, small group discussion (based on age) concerning self-testing CG - Attended camp, no specialized education | Trained observer, supervisor (IG); NR (CG) 1–2, 15–30 min. sessions Immediate | Self-management skills (absolute syst. error in SMBG) - No significant difference between groups when comparing baseline to post-intervention Self-management skills (random errors) - No significant difference between groups when comparing baseline to post-intervention Psychosocial (IBC: adolescent negative communication) - BFST significantly decreased compared to other groups at 6 and 12 mo. Psychosocial (IBC: mother negative communication) - BFST significantly improved compared to other groups at 6 and12 mo. Psychosocial (IBC: negative reciprocity) - BFST families significant improvement compared to other groups at 6 and 12 mo. Psychosocial (IBC: problem resolution) - BFST families significant improvement compared to other groups at 6 and 12 mo.
Wysocki^82^ 2007 | 104 RCT (parallel) Diabetes center | IG1 - Standard care, plus 12 90-min. meetings within 6 mo., groups included 3–5 families, meetings emulated a common mental health service for families of chronically ill teens, content followed chapters of an ADA curriculum for teens, family communication and conflict resolution skills were excluded IG2 - Standard care, plus 12 behavioral family systems therapy sessions, 4 components—problem-solving training, communication skills, cognitive restructuring, functional and structural family therapy CG - Standard care | Nurse (IG1); psychologist (IG2 and CG); diabetes educator, pediatric endocrinologist (CG) 6 mo. 12 mo. | HbA1c - BFST-D significantly lower than CG (p<0.05) at 6, 9, 12, 15, and 18 mo.; BFST-D significantly lower than ES (p<0.05) at 9, 15, and 18 mo. Self-management/adherence - BFST-D significantly better scores than SC at each followup, but no significant difference between BFST-D and ES or between ES and SC at any time, significant main effects for groups (p<0.03) but group-by-time interaction not significant Psychosocial (family/social relationships) - BFST-D significantly lower than CG and ES only at 6 mo. significant main effect for groups (p<0.03), but group × time interaction effect not significant
Wysocki^83^ 2000 | 119 RCT (parallel) Doctor's office | IG1 - Standard care, plus 10 sessions of BFST, 4 components—problem-solving training, communication skills, cognitive restructuring, functional and structural family therapy, families received individualized plans, session activities included problem solving discussions, feedback, modeling, rehearsal, homework IG2 - Standard care, plus 10 group meetings, emphasized education and social support, 2–5 families per group, family communication and conflict resolutions skills excluded CG - Standard care | Psychologist (IG1); social worker, health educator (IG2); physician (CG) 3 mo. 12 mo. | HbA1c - No significant differences between groups at 3 mo. Self-management/adherence - Some improvement in younger children at 3 mo. (n.s.) but effect dissipated by 6 mo. Psychosocial (PARQ extreme beliefs) - BFST significantly lower scores compared to either group at 3 mo. FU (p = 0.006)
Zorumski^84^ 1997 | 56 CCT Day camp (IG); doctor's office (CG) | IG - 1-wk. camp, covered all aspects of diabetic self-management, used active participation and educational presentations, observed and demonstrated behaviors CG - Standard care | Diabetes educator, health care professional (IG); physician (CG) 1 wk. (IG); NR (CG) 4 mo. | HbA1c - No statistically significant difference between groups Psychosocial (self-perception) - CG statistically higher score than IG (p<0.05) at 4 mo. Psychosocial (self-management) - No statistically significant difference between groups

BG = blood glucose; carb = carbohydrate; CG = comparison group; d = day; DKA = diabetic ketoacidosis; IG = intervention group; NA = not applicable; NR = not reported; NS = not significant; SMBG = self-monitoring of blood glucose; Tx = treatment

Table F3 Methodological quality of uncontrolled before-and-after and cohort studies assessing the effectiveness of diabetes education for children with type 1 diabetes and their families

| Selection bias | | | Allocation bias | | Confounding | | | | Blinding | | Data collection methods | | | Withdrawals/dropouts | | Intervention integrity
Author Year | Representative of target population? | % agreed to participate | Rating | Study design | Rating | Between group differences prior to intervention? | Relevant confounders specified | Confounders adequately managed in analysis? | Rating | Assessor(s) blinded to intervention status? | Rating | Data collection tools valid? | Data collection tools reliable? | Rating | % participants completed | Rating | % participants receiving intervention
Caravalho^11^ 2000 | Somewhat likely | <60 | W | Uncontrolled before-and-after study | W | NA | Age, sex, duration, SES | NA | M | No | W | Yes | Yes | S | 60–79 | M | ≥80
Christensen^12^ 2000 | Not likely | ≥80 | W | Uncontrolled before-and-after study | W | NA | Sex, duration | NA | W | No | W | No | No | W | ≥80 | S | ≥80
Greco^20^ 2001 | Somewhat likely | 60–79 | M | Uncontrolled before-and-after study | W | NA | Age, sex, duration, SES | NA | M | NR | W | Yes | Yes | S | ≥80 | S | ≥80
Harkavy^27^ 1983 | Somewhat likely | NR | M | Uncontrolled before-and-after study | W | NA | Age, sex, duration, SES | NA | M | NA | W | No | No | W | ≥80 | S | ≥80
Harris^28^ 2005 | Not likely | <60 | W | Uncontrolled before-and-after study | W | NA | Age, sex, SES | NA | W | NR | W | Yes | Yes | S | ≥80 | S | ≥80
Hill^29^ 2006 | Somewhat likely | NR | W | Prospective cohort with concurrent control | M | Can't Tell | Age, sex | NA | W | No | W | Yes | Yes | S | <60 | W | ≥80
Karaguzel^34^ 2005 | Not likely | NR | W | Uncontrolled before-and-after study | W | NA | Age, sex, duration | NA | W | No | W | No | No | W | ≥80 | S | ≥80
Kemp^35^ 1986 | Somewhat likely | NR | W | Uncontrolled before-and-after study | W | NA | Age | NA | W | No | W | Yes | Yes | S | NR | W | ≥80
Koontz^37^ 2002 | Somewhat likely | 60–79 | M | Uncontrolled before-and-after study | W | NA | Age, sex, duration, SES | NA | S | No | W | Yes | Yes | S | <60 | W | ≥80
Lawson^39^ 2000 | Somewhat likely | NR | W | Retrospective cohort | W | No | Age, duration | NA | W | NR | W | Yes | Yes | S | ≥80 | S | ≥80
Likitmaskul^40^ 2002 | Very likely | NR | M | Prospective cohort with historical control | W | No | Age, sex, duration | NA | W | No | W | Yes | Yes | S | ≥80 | S | ≥80
Lipman^41^ 1988 | Somewhat likely | ≥80 | M | Retrospective cohort | W | No | Age, sex, duration | NA | W | No | W | Yes | Yes | S | ≥80 | S | <60
Marteau^44^ 1987 | Not likely | NR | W | Uncontrolled before-and-after study | W | NA | None | NA | W | No | W | No | No | W | ≥80 | S | ≥80
Monaco^50^ 1996 | Very likely | NR | M | Uncontrolled before-and-after study | W | No | Age, sex | NA | W | No | W | Yes | Yes | S | ≥80 | S | ≥80
Nordfeldt^54^ 1999 | Very likely | ≥80 | S | Prospective cohort with historical controls | W | NA | Age, sex, duration | NA | W | No | W | No | No | W | ≥80 | S | ≥80
Nordfeldt^53^ 2002 | Very likely | NR | M | Uncontrolled before-and-after study | W | NA | Age, duration (average) | NA | W | No | W | Yes | Yes | S | NR | W | 60–79
Povlsen^61^ 2005 | Somewhat likely | NR | W | Uncontrolled before-and-after study | W | NA | Age, duration | NA | W | NR | W | Yes | No | W | 60–79 | M | ≥80
Schlundt^64^ 1996 | Somewhat likely | NR | W | Uncontrolled before-and-after study | W | NA | Age, sex, duration | NA | W | No | W | Yes | Yes | S | <60 | W | ≥80
Shobhana^65^ 1997 | Somewhat likely | NR | M | Uncontrolled before-and-after study | W | NA | None | NA | W | NR | W | No | No | W | <60 | W | ≥80
Siminerio^66^ 1999 | Somewhat likely | NR | M | Prospective cohort with concurrent control group | W | No | Sex, age, SES, duration | NA | M | NR | W | Yes | Yes | S | ≥80 | S | ≥80
Smith^68^ 1991 | Somewhat likely | 60–79 | M | Uncontrolled before-and-after study | W | NA | Age, sex, duration | NA | W | NA | W | No | Yes | W | ≥80 | S | ≥80
Smith^67^ 1993 | Somewhat likely | ≥80 | M | Uncontrolled before-and-after study | W | NA | Age, sex, duration, SES | NA | M | No | W | Yes | Yes | S | <60 | W | ≥80
Srinivasan^69^ 2004 | Very likely | NR | M | Prospective cohort with concurrent control group | W | No | Age, A1c, SES | NA | W | No | W | Yes | Yes | S | ≥80 | S | ≥80
Templeton^73^ 1988 | Somewhat likely | NR | W | Uncontrolled before-and-after study | W | NA | Age, duration | NA | W | No | W | No | No | W | ≥80 | S | ≥80
Verrotti^75^ 1993 | Somewhat likely | NR | W | Uncontrolled before-and-after study | W | No | Age, sex, duration, SES | NA | M | NR | W | Yes | Yes | S | ≥80 | S | ≥80
von Sengbusch^77^ 2006 | Somewhat likely | ≥80 | M | Uncontrolled before-and-after study | W | Yes | Age, sex, duration, family structure | NA | M | NR | W | Yes | Yes | S | ≥80 | S | ≥80
Vyas^78^ 1988 | Very likely | NR | M | Uncontrolled before-and-after study | W | NA | Age, sex, duration | NA | W | No | W | Yes | Yes | S | 60–79 | M | ≥80

M = moderate; NA = not applicable; NR = not reported; SES = socioeconomic status; W = weak