# Appendix E. Secondary Studies

Table E1. Description of secondary studies

Primary report: Anderson BJ, Brackett J, Ho J, et al. An office-based intervention to maintain parent-adolescent teamwork in diabetes management. Impact on parent involvement, family conflict, and subsequent glycemic control. Diabetes Care 1999;22(5):713–21. Associated publications: Anderson BJ, Brackett J, Ho J, et al. An intervention to promote family teamwork in diabetes management tasks: relationships among parental involvement, adherence to blood glucose monitoring, and glycemic control in young adolescents with type 1 diabetes. In: Drotar D ed. Promoting adherence to medical treatment in chronic childhood illness: concepts, methods, and interventions. Mahwah, NJ: Lawrence Erlbaum Associates Publishers; 2000. p. 347–65.
Primary report: Anderson BJ, Wolf FM, Burkhart MT, et al. Effect of peer-group intervention on metabolic control of adolescents with IDDM. Randomized outpatient study. Diabetes Care 1989;12(3):179–83. Associated publications: Anderson BJ, Burkhart M, Tomlin P, et al. Behavioral and metabolic effects of a controlled self-efficacy group intervention with diabetic adolescents. Diabetes 1986;35(Suppl 1):A78.
Primary report: Brown SJ, Lieberman D, Germeny B, et al. Educational video game for juvenile diabetes: results of a controlled trial. Med Inform (Lond) 1997;22(1):77–89. Associated publications: Lieberman DA. Health education video games for children and adolescents: theory, design, and research findings. Paper presented at the 48th Annual Meeting of the International Communication Association; 1998 July 20–24; Jerusalem, Israel.
Primary report: Grey M, Boland E, Davidson, et al. Coping skills training for youth with diabetes mellitus has long-lasting effects on metabolic control and quality of life J Pediatr 2000;137:107-03. Associated publications: Grey M, Yu C, Boland E, et al. Short-term effects of coping skills training as adjunct to intensive therapy in adolescents. Diabetes Care 1998;21:902–08.
Primary report: Hackett AF, Court S, Matthews JNS, et al. Do education groups help diabetics and their parents. Arch Dis Child 1989;64(7):977–1003. Associated publications: Hackett A. Food intake of children with diabetes mellitus before and after a programme of education [dissertation]. United Kingdom: University of Newcastle Upon Tyne; 1987.
Primary report: Harris M, Harris BS, Mertlich D. Brief report: in-home family therapy for adolescents with poorly controlled diabetes: failure to maintain benefits at 6-month follow-up. J Pediatr Psychol 2005;30(8):683–8. Associated publications: Harris M, Mertlich D. Piloting home-based behavioral family systems therapy for adolescents with poorly controlled diabetes. Child Health Care 2003;32(1):65–79.
Primary report: Hoff AL, Mullins LL, Gillaspy SR, et al. An intervention to decrease uncertainly and distress among parents of children newly diagnosed with diabetes: a pilot study. Fam Syst Health 2005;23(3):329–42. Associated publications: Hoff AL. An intervention to decrease illness uncertainty and psychological distress among parents of children newly diagnosed with type 1 diabetes: a randomized clinical trial [dissertation]. Oklahoma: Oklahoma State University; 2003.
Primary report: Laffel LMB, Vangsness L, Connell A, et al. Impact of ambulatory family-focused teamwork intervention on glycemic control in youth with type 1 diabetes. J Pediatr 2003;142(4):409–16. Associated publications: Butler D, Volkening LK, Milaszewski K, et al. Family-focused teamwork intervention for youth with type 1 diabetes (T1DM) positively impacts A1c and quality of life (QoL): results of a 2-year randomized controlled trial. Diabetes 2006;55:A421-A421. Laffel LMB, Connell AJ, Vangsness LJ, et al. Family-focused ambulatory teamwork (TW) intervention improves a1c compared with standard care (SC) in youth with type 1 diabetes (T1DM): results of a randomized trial. Diabetes 2002;51:A424.
Primary report: Nordfeldt S Johansson C Carlsson E Hammersjo J. Persistent effects of a pedagogical device targeted at prevention of severe hypoglycaemia: a randomized, controlled study. Acta Paediatrica 2005;94(10):1395–401. Associated publications: Nordfeldt S, Johansson C, Carlsson E, et al. Prevention of severe hypoglycaemia in type I diabetes: a randomised controlled population study. Arch Dis Child 2003;88(3):240–5.
Primary report: Siminerio LM , Charron PD, Banion C, et al. Comparing outpatient and inpatient diabetes education for newly diagnosed pediatric patients. Diabetes Educator 1999;25(6):895–906. Associated publications: Siminerio LM. Comparing outpatient to inpatient diabetes education for newly diagnosed pediatric patients: an exploratory study [dissertation]. Pennsylvania: Pennsylvania State University; 1998.
Primary report: Wysocki T, Harris M, Greco P, et al. Randomized, controlled trial of behavior therapy for families of adolescents with insulin-dependent diabetes mellitus. J Pediatr Psychol 2000;25(1):23–33. Associated publications: Harris M, Greco P, Wysocki T, et al. Family therapy with adolescents with diabetes: a litmus test for clinically meaningful change. Fam Syst Health 2001;19:159–68. Wysocki T, Greco P, Harris M, et al. Behavior therapy for families of adolescents with diabetes: maintenance of treatment effects. Diabetes Care 2001;24:441–6. Wysocki T, Greco P, Harris MA, et al. Behavioral Family Systems Therapy for adolescents with diabetes. In: Drotar D ed. Promoting adherence to medical treatment in chronic childhood illness: concepts, methods, and interventions. Mahwah, NJ: Lawrence Erlbaum Associates Publishers; 2000. p. 367–81. Wysocki T, Miller KM, Greco P, et al. Behavior therapy for families of adolescents with diabetes: effects on directly observed family interactions. Behav Ther 1999;30(3):507–25.
Primary report: Wadham C, Hassler Hurst J, Almond J, et al. Integrating group education into paediatric diabetes care: FACTS. J Diabetes Nurs 2005;9(6):221–5. Associated publications: Murphy HR, Wadham C, Rayman G, et al. Integrating pediatric diabetes education into routine clinical care: The Families, Adolescents and Children's Teamwork Study (FACTS). Diabetes Care 2006;29(5):1177.
Primary report: Sundelin J, Forsander G, Mattson SE. Family-oriented support at the onset of diabetes mellitus: a comparison of two group conditions during 2 years following diagnosis. Acta Paediatrica 1996;85:49–55. Associated publications: Forsander G, Malmodin B, Eklund C, et al. Relationship between dietary intake in children with diabetes mellitus type I, their management at diagnosis, social factors, anthropometry and glycaemic control. Scand J Nutrition/Naringsforskning 2003;47(2):75–84. Forsander G, Persson B, Sundelin J, et al. Metabolic control in children with insulin-dependent diabetes mellitus 5 y after diagnosis. Early detection of patients at risk for poor metabolic control. Acta Paediatrica 1998;87(8):857–64.
Primary report: Wysocki T, Harris MA, Buckloh LM, et al. Randomized trial of behavioral family systems therapy for diabetes: maintenance of effects on diabetes outcomes in adolescents. Diabetes Care 2007;30(3):555–60. Associated publications: Wysocki T, Harris MA, Buckloh LM, et al. Effects of behavioral family systems therapy for diabetes on adolescents' family relationships, treatment adherence, and metabolic control. J Pediatr Psychol 2006;31(9):928–38. Wysocki T, Harris MA, Buckloh LM, et al. Effects of behavioral family systems therapy on adolescents' diabetes outcomes. Diabetes 2005;54(Suppl 1):A19.