# Appendix D. Excluded Studies

After screening the full-text of studies that were potentially relevant to this review, 327 were excluded from this review. The studies are grouped by reason for exclusion. In addition, there were 46 studies that were unavailable for retrieval.

## Topic

The purpose of this review was to answer questions regarding the effectiveness of diabetes and medical nutrition therapy education for children with type 1 diabetes mellitus and their families. The following 50 studies were excluded because they addressed different topics.

### References

1 Diabetes Care Centre at Texas Children's Hospital. (1994). Effect of intensive diabetes treatment on the development and progression of long-term complications in adolescents with insulin-dependent diabetes-mellitus—diabetes control and complications trial. J Pediatr.
2 IHS getting healthy returns in statewide diabetes initiative: early emphasis on education produces solid improvement. Dis Manag Advis 2002;8(6):85–9.
3 Aguilar MI, Hart R. Oral anticoagulants for preventing stroke in patients with non-valvular atrial fibrillation and no previous history of stroke or transient ischemic attacks. Cochrane Database of Systematic Reviews. 2005(3):CD001927.
4 Allen HF, Yarnie S, Murray MA, et al. (2000). Is telephone care an effective tool for management of children with Type 1 diabetes? [abstract]. Diabetes.
5 Brandt P, Watts G. (2006). Bridging science and practice: four collaborative clinical projects: a clinic based protocol for teens with diabetes and their parents. Commun Nurs Res.
6 Briery BG. Psychosocial sequelae of relaxation training and peer interaction for children with diabetes [dissertation]. Hattiesburg, MS: University of Southern Mississippi; 2000.
7 Campaigne BN, Gilliam TB, Spencer ML, et al. (1983). The effects of a physical-activity program on children with insulin dependent diabetes-mellitus [abstract]. Med Sci Sports Exerc.
8 Carson C. (2002). Educating adolescents with type 1 diabetes about drug use. Journal of Diabetes Nursing.
9 Challener J, Ozen S, Barnes ND. (1989). The memory blood glucose reflectance meter: a useful educational tool for the diabetic adolescent?. Practical Diabetes.
10 Charron Prochownik D, Sereika SM, Hannan MF, et al. (2006). Reproductive health education for adolescent girls with diabetes (Ready-Girls): sustaining long-range outcomes [abstract]. Diabetes.
11 Diabetes Control and Complications Trial Research Group. (1994). Effect of intensive diabetes treatment on the development and progression of long-term complications in adolescents with insulin-dependent diabetes mellitus: Diabetes Control and Complications Trial. J Pediatr.
12 Diabetes Control and Complications Trial Research Group. (1995). Progression of retinopathy with intensive versus conventional treatment in the Diabetes Control and Complications Trial. Ophthalmology.
13 George CK. Video in pediatric patient education: the role of formal features in the relationship of intervention, knowledge, and anxiety [dissertation]. Austin, TX: University of Texas at Austin; 1992.
14 Hanauer D, Wentzell K, Tovar A, et al. (2006). Parent and youth assessments of a handheld wireless device to enhance diabetes mellitus management. Arch Pediatr Adolesc Med.
15 Herskowitz RD. (1990). Outward bound, diabetes and motivation: experiential education in a wilderness setting. Diabet Med.
16 Hillson RM. (1984). Diabetes outward bound mountain course, Eskdale, Cumbria. Diabet Med.
17 Huttunen NP, Lankela SL, Knip M, et al. (1989). Effect of once-a-week training program on physical fitness and metabolic control in children with IDDM. Diabetes Care.
18 Jones EM. The efficacy of intensive individual play therapy for children diagnosed with insulin-dependent diabetes mellitus [dissertation]. Denton, TX: University of North Texas; 2000.
19 Kerr D, Kerr S. (1988). Diabetic camps for children—effects on control and hypoglycaemia. Practical Diabetes.
20 Kuno T, Tasaki H, Miyazaki S. (1996). [Continuous subcutaneous insulin injection for self-care of young patients with insulin-dependent diabetes mellitus]. Acta Paediatr Jpn.
21 Laffel LM, Brackett J, Ho J, et al. (1998). Changing the process of diabetes care improves metabolic outcomes and reduces hospitalizations. Qual Manag Health Care.
22 Landt KW, Campaigne BN, James FW, et al. (1985). Effects of exercise training on insulin sensitivity in adolescents with type I diabetes. Diabetes Care.
23 Lawson ML, Cohen N, Richardson C, et al. (2005). A randomized trial of regular standardized telephone contact by a diabetes nurse educator in adolescents with poor diabetes control. Pediatr Diabetes.
24 Lee PD. (1992). An outpatient-focused program for childhood diabetes: design, implementation, and effectiveness. Tex Med.
25 Lieberman D. (2001). Management of chronic pediatric diseases with interactive health games: theory and research findings. J Ambulatory Care Manage.
26 Mackowiak L. Education record for new-onset pediatric diabetes. Diabetes Educ 1996;22(4):345, 347, 349–50 passim.
27 Mann LH. Effects of biofeedback-assisted deep muscle relaxation training on blood glucose levels in female adolescents with type I diabetes [dissertation]. Amherst, MA: University of Massachusetts; 1991.
28 Marrero DG, Kronz KK, Golden MP, et al. (1989). Clinical evaluation of computer-assisted self-monitoring of blood glucose system. Diabetes Care.
29 Melchionne FM. (1993). Children with diabetes mellitus: health and education teams. Holist Nurs Pract.
30 Miller SG. (1996). Family therapy for recurrent diabetic ketoacidosis: treatment guidelines. Fam Syst Health.
31 Orr PM, McGinnis M, Hudson LR, et al. (2006). A focused telephonic nursing intervention delivers improved adherence to A1c testing. Dis Manag.
32 Pinosa C, Marchand C, Tubiana Rufi N, et al. (2004). The use of concept mapping to enlighten the knowledge networks of diabetic children: a pilot study. Diabetes Metab.
33 Price KJ, Lang JD, Eiser C, et al. (1993). Prescribed versus unrestricted carbohydrate diets in children with type 1 diabetes. Diabet Med.
34 Roberts L, Jones TW, Fournier P. (2002). Exercise training and glycemic control in adolescents with poorly controlled type 1 diabetes mellitus. J Pediatr Endocrinol Metab.
35 Rogers DG. (1994). The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. Clin Pediatr (Phila).
36 Romanian Young Diabetics Study Team (RYDST). (1997). Mixtard 30 HM Penfill insulin treatment in selected young insulin-dependent diabetes mellitus patients. Romanian Young Diabetics Study Team (RYDST). Rom J Intern Med.
37 Rosenfalck AM, Bendtson I. (1993). The Diva(TM) system, a computerized diary, used in young type 1 diabetic patients. Diabetes Metab.
38 Ryden O, Nevander L, Johnsson P, et al. (1994). Family therapy in poorly controlled juvenile IDDM: effects on diabetic control, self-evaluation and behavioural symptoms. Acta Paediatr.
39 Sar V, Akyuz G, Kugu N, et al. (2006). Axis I dissociative disorder comorbidity in borderline personality disorder and reports of childhood trauma. J Clin Psychiatry.
40 Schafer LC, McCaul KD, Glasgow RE. (1986). Supportive and nonsupportive family behaviors: relationships to adherence and metabolic control in persons with type I diabetes. Diabetes Care.
41 Siarkowski AK, Pidgeon V. (1991). Documentation of discharge teaching before and after use of a discharge teaching tool. J Pediatr Nurs.
42 Smith CA, Kennedy DM, Lahoz MR, et al. Creating an academic and rural community network to improve diabetes care. In: Issues Affecting Rural Communities (II). Proceedings of the International Conference [on] Rural Communities & Identities in the Global Millennium; 2000 May 1–5; Nanaimo, BC. Nanaimo (BC): Rural Communities Research and Development Centre, Malaspina University College; 2000.
43 Smith LJ. Type I diabetes mellitus: dependent care agents' participation in decision making compared to their participation in diabetes education [master's thesis]. Columbia, OH: University of Missouri; 1991.
44 The Diabetes Control and Complications Trial. The effect of intensive diabetes treatment on the progression of diabetic retinopathy in insulin-dependent diabetes mellitus. Arch Ophthalmol 1995;113(1):36–51.
45 The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group. (2000). Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy [erratum appears in N Engl J Med 2000;342(18):1376]. N Engl J Med.
46 The Diabetes Control and Complications Trial Research Group. (1993). The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. N Engl J Med.
47 Vanelli M, Chiari G, Ghizzoni L, et al. (1999). Effectiveness of a prevention program for diabetic ketoacidosis in children: an 8-year study in schools and private practices. Diabetes Care.
48 Ward J. (1999). Kid stuff. Teaching children about diabetes management. Adv Nurse Pract.
49 Warpeha J. Design and implementation of an outdoor forestry program for children with diabetes [dissertation]. Orono, ME: The University of Maine; 1998.
50 Yopp JM. The impact of family functioning on treatment adherence and metabolic control for adolescents with poorly controlled type 1 diabetes [dissertation]. Mount Pleasant, MI: Central Michigan University; 2004.

## Study Design

The review included studies that had the following study designs: randomized controlled trial (parallel or crossover), clinical controlled trial, cohort study, case-control study, interrupted time series, before-after study with concurrent control group, case series, and uncontrolled before-after study. The following 93 studies were systematic reviews, descriptive studies, or case reports.

### References

1 Boost glycemic control in teen diabetics through “family focused teamwork.” Dis Manag Advis 2003;9(9):120–2.
2 Developing social skills: issues for adolescents with chronic illnesses and disabilities. CYDLINE Reviews. Minnesota University, MN: National Center for Youth with Disabilities; 1993.
3 Interactive games teach kids diabetes self-management skills. Diabetes Dateline 1999-2000:6.
4 Issues in nutrition for adolescents with chronic illnesses and disabilities. CYDLINE reviews. Minnesota University, MN: National Center for Youth with Disabilities; 1992.
5 Recreation and leisure: issues for adolescents with chronic illnesses and disabilities. CYDLINE Reviews. Minnesota Univ., MN: National Center for Youth with Disabilities, 92.
6 Self-esteem: issues for adolescents with chronic illnesses and disabilities. CYDLINE reviews. Minnesota University, MN: National Center for Youth with Disabilities; 1993.
7 Abdullah M. (1989). Outpatient management of childhood diabetes: experience of a pediatric diabetes clinic at King Khalid University Hospital, Riyadh. Ann Saudi Med.
8 Acerini CL, Deeb A. (2004). New approaches to insulin therapy in children and adolescents with type 1 diabetes. British Journal of Diabetes & Vascular Disease.
9 Adkins JW, Storch E, Lewin AB, et al. (2006). Home-based behavioral health intervention: use of a telehealth model to address poor adherence to type-1 diabetes medical regimens. Telemed J E Health.
10 Adler DE, Milhorat TH, Miller JI. (1998). Treatment of rhinocerebral mucormycosis with intravenous interstitial, and cerebrospinal fluid administration of amphotericin B: Case report. Neurosurgery.
11 Ahmann A. (1998). Comprehensive management of the hospitalized patient with diabetes. Endocrinologist.
12 Anderson K. (1997). An evaluation of an adolescent diabetes education program. Canadian Journal of Diabetes Care.
13 Arkya RA. (1984). Nutrition therapy for the child and adolescent with type-I diabetes-mellitus. Pediatr Clin North Am.
14 Baker SD. (1995). Software review. Diabetes mellitus: a learning program for patients and their families. Comput Nurs.
15 Barry B. (1995). Games and activities to teach children about diabetes and nutrition. Diabetes Educ.
16 Bateman C. (2007). Unique cartoon book to uplift/educate child diabetics. S Afr Med J.
17 Boswell EJ. (1987). A team approach. Selecting teaching strategies to promote patient adherence. Diabetes Educ.
18 British Diabetic Association. Education and Professional Care Section and Medical and Scientific Section; 1995 Mar 30–31; Coventry. Diabet Med 1995;12(Suppl 4).
19 Brown SA. (1990). Studies of educational interventions and outcomes in diabetic adults: a meta-analysis revisited. Patient Educ Couns.
20 Centre for Reviews, Dissemination. Computerized knowledge management in diabetes care [abstract]. Database of Abstracts of Reviews of Effects 2007;1.
21 Centre for Reviews, Dissemination. Educational and psychosocial programmes for adolescents with diabetes: approaches, outcomes and cost-effectiveness [abstract]. Database of Abstracts of Reviews of Effects 2007;1.
22 Centre for Reviews, Dissemination. Effects of educational and psychosocial interventions for adolescents with diabetes mellitus: a systematic review [abstract]. Database of Abstracts of Reviews of Effects 2007;1.
23 Centre for Reviews, Dissemination. Increasing diabetes self-management education in community settings: a systematic review [abstract]. Database of Abstracts of Reviews of Effects 2007;1.
24 Centre for Reviews: Dissemination. Clinical trials of interactive computerized patient education: implications for family practice [abstract]. Database of Abstracts of Reviews of Effects 2007;1.
25 Citrin WS, Furman SG, Girden E. (1983). Diabetes in adolescence—group assertiveness training and the traditional rap group [abstract]. Diabetes.
26 Crowe L, Billingsley JI. (1990). The rowdy reactors: maintaining a support group for teenagers with diabetes. Diabetes Educ.
27 Dafogianni C , Kafourou A. A new education and training model for adolescents with IDDM. ICUs & Nursing Web Journal 2001;(7):1–19.
28 Davidson M, Boland E, Grey M. (1997). Teaching teens to cope: coping skills training for adolescents with insulin-dependent diabetes mellitus. J Soc Pediatr Nurs.
29 Detzer MJ, Baird AC, Kendall MC, et al. (2004). Star: a group mentoring program for type 1 diabetes mellitus (T1dm) adolescents and their parents in a rural setting [abstract]. Diabetes.
30 Dorman PM. (1989). A hospital-based day camp for children with diabetes. Diabetes Educ.
31 Engvall JC. (1994). Use of computer-assisted instruction in diabetes education. Diabetes Educ.
32 Evert A. (2005). Nutrition management tools and techniques for working with students with diabetes. School Nurse News.
33 Evert A. (2006). Real world meal planning strategies for children and adolescents with diabetes. School Nurse News.
34 Farquhar JW. (1989). Use of a teleport system in parent and adolescent support. Diabet Med.
35 Finney JW, Bonner MJ. (1992). The influence of behavioural family intervention on the health of chronically ill children. Behav Change.
36 Francis GL, Grogan D, Hardy L, et al. (1990). Group psychotherapy in the treatment of adolescent and preadolescent military dependents with recurrent diabetic ketoacidosis. Mil Med.
37 Gray DL, Marrero DG, Godfrey C, et al. (1988). Chronic poor metabolic control in the pediatric population: a stepwise intervention program. Diabetes Educ.
38 Grey M. (1999). Home based care improved glycaemic control and was cost effective in children with type 1 diabetes [commentary on Dougherty G, Schiffrin A, White D, et al. Home-based management can achieve intensification cost-effectively in type 1 diabetes. Pediatrics 1999 Jan;103:122–8]. Evid Based Nurs.
39 Grey M, Urban A, Lindemann E, et al. (2003). Can coping skills training for school-aged youth and their parents improve psychosocial well-being and metabolic control? [abstract]. Diabetes.
40 Hall J. (1995). Diabetes-mellitus—a program to inform patients and families. J Fam Pract.
41 Harrigan JF, Faro BZ, VanPutte A, et al. (1987). The application of locus of control to diabetes education in school-aged children. J Pediatr Nurs.
42 Hatcher T. (1990). Residential weekend for children with diabetes. Diabet Med.
43 Hernandez C. (2004). Family focused teamwork prevented deterioration in diabetes control in children and adolescents [abstract]. Evid Based Nurs.
44 Hillson R. (1998). British Diabetic Association Outward Bound courses: learning by doing. Practical Diabetes International.
45 Hord SM, Huling Austin L. (1985). Acquiring expertise. Diabetes Educ.
46 Jack L, Liburd L, Vinicor F, et al. (1999). Influence of the environmental context on diabetes self-management: a rationale for developing a new research paradigm in diabetes education. Diabetes Educ.
47 Jaworowski S, Leiberman E, Miller S, et al. (1993). Assertive outreach follow-up for adolescents with IDDM. Diabetes Care.
48 Johnston A, Maclean M. (1992). The team approach to practical management of childhood diabetes mellitus: a case study. Eur J Clin Nutr.
49 Jovanovic L, Peterson CM. (1984). A comparison of eight educational programs. Diabetes Educ.
50 Knowles J, Waller H, Eiser C, et al. (2006). The development of an innovative education curriculum for 11–16 yr old children with type 1 diabetes mellitus (T1DM). Pediatr Diabetes.
51 Laron Z, Faiman G, Flexer Z, et al. (1987). Use of a computer program in the treatment and education of young diabetics. Acta Paediatr Jpn.
52 Malasanos T. (2005). FITE diabetes: Florida Initiative in Telehealth and Education. Approach to diabetes care for children [abstract]. Practical Diabetes International.
53 Malasanos TH, Patel BD, Klein J, et al. (2005). School nurse, family and provider connectivity in the FITE diabetes project. J Telemed Telecare.
54 McSeveney ED. (1987). Learning about diabetes: the production and evaluation of a teaching package for insulin dependent diabetic children. Hum Nutr Appl Nutr.
55 Mennick F. (2003). Nurses teach families to heal. Nurs Spectr (Gt Phila Tri State Ed).
56 Moore KE, Geffken GR, Royal GP. (1995). Behavioral intervention to reduce child distress during self-injection. Clin Pediatr (Phila).
57 Murphy M, Risser N. (2000). Adolescents with diabetes [abstract]. Nurse Pract.
58 Nansel TR, Iannotti RJ, Simons, et al. (2005). Short-term outcomes of a diabetes “personal trainer” intervention for youth with type 1 diabetes [abstract]. Diabetes.
59 National Institutes of Health (DHEW): Indian Health Service. Family food choices: a guide to weight and diabetes control. Rockville, MD: Indian Health Service (PHS/HSA), 1986; NIH-5-P60-AM20572.
60 Niihira S, Inada H, Tei S, et al. (1987). Application of computer programs in the management of diabetic children. Acta Paediatr Jpn.
61 Padgett D, Mumford E, Hynes M, et al. (1988). Meta-analysis of the effects of educational and psychosocial interventions on management of diabetes mellitus. J Clin Epidemiol.
62 Paterson BL. (2006). Multisystemic therapy improved adherence to blood glucose testing in adolescents with type 1 diabetes [abstract]. Evid Based Nurs.
63 Peery AI. Case study 4: nutrition survival skills for diabetes: a personal experience. In: Bolin JN, Gaubeca VB, eds. Handbook of diabetes management. New York, NY: Springer Science and Business Media; 2006. p. 367–9.
64 Pichert JW, Flannery ME, Davis DD, et al. (1995). Impact of problem-based instruction on knowledge, blood-glucose, and self-efficacy in adolescents with Iddm [abstract]. Diabetes.
65 Pichert JW, Meek JM, Schlundt DG, et al. (1994). Impact of anchored instruction on problem-solving strategies of adolescents with diabetes. J Am Diet Assoc.
66 Pichert JW, Snyder GM, Kinzer CK, et al. (1992). Sydney meets the ketone challenge—a videodisc for teaching diabetes sick-day management through problem solving. Diabetes Educ.
67 Remley D, Cook NM. Nutrition update. Meal planning self-efficacy index for adolescents with diabetes. Diabetes Educ 1999;25(6): 883–4, 886, 888–90.
68 Rheeder P. (2006). Diabetes management in family practice. South African Family Practice.
69 Richmond J. (1994). In the picture for learning. Use of pictorial learning for young children with diabetes. Prof Nurse.
70 Robnett M, Carreon E, Kaufman F, et al. (1991). Grandparent/caretaker education session. Diabetes Educ.
71 Roszler J. Getting the diabetes information you need. Diabetes Self Manag 2004;21(3):47–9, 51–2.
72 Sherifali D. (2004). A case manager plus psychoeducation reduced adverse outcomes in youth with type 1 diabetes [abstract]. Evid Based Nurs.
73 Smith AC, Batch J, Lang E, et al. (2003). The use of online health techniques to assist with the delivery of specialist paediatric diabetes services in Queensland. J Telemed Telecare.
74 Sterrett B, Lewis MA. (1984). DAE (Dog Assisted Education)... teaches children with diabetes how to cope. Diabetes Educ.
75 Sumner J, Dyson PA. (2004). An intensive education programme for people with type 1 diabetes. Nurs Times.
76 Swift CS, Boucher JL. (2006). Nutrition therapy for the hospitalized patient with diabetes. Endocr Pract.
77 The DCCT Research Group. (1989). Implementation of a multicomponent process to obtain informed consent in the Diabetes Control and Complications Trial. Control Clin Trials.
78 Travis LB. (1992). “Educating” the person with diabetes in an ambulatory setting. Tex Med.
79 Travis LB, Schreiner B. (1984). Camps for children with diabetes: a philosophy and its application. Diabetes Educ.
80 Tuchinda C, Vanaprapa N, Nirapik S, et al. (1989). Diabetic education, special consideration of Oriental patients. Indian J Pediatr.
81 Tumini S, Anzellotti MT, Chiarelli F. (2003). Camps for children with T1DM. Acta Biomed Ateneo Parmense.
82 Tupling H. (1984). The role of the educational psychologist. Diabetes Educ.
83 Udezue E, Nashwan R, Azim A, et al. (2005). The impact of a multi-disciplinary management approach on diabetic control in young Saudi patients. Ann Saudi Med.
84 Urban AD, Rearson M, Murphy K. (1998). The Diabetes Center home care nurse: an integral part of the diabetes team. Diabetes Educ.
85 Vanelli M, Corchia M, Iovane B, et al. (2006). Outside-hospital assistance for children and adolescents with type 1 diabetes mellitus. Acta Biomed Ateneo Parmense.
86 Waldron S, Hanas R, Palmvig B. (2002). How do we educate young people to balance carbohydrate intake with adjustments of insulin?. Horm Res.
87 Waller A, Franklin V, Pagliari C, et al. (2006). Participatory design of a text message scheduling system to support young people with diabetes. Health Informatics Journal.
88 Watkinson M. (2001). Intensive diabetes management plus coping skills training improved metabolic control and quality of life in adolescents...commentary on Grey M, Boland EA, Davidson M et al. Coping skills training for youth with diabetes mellitus has long-lasting effects on metabolic control and quality of life. J Pediatrics 2000;137:107–13. Evid Based Nurs.
89 Weinger K. (1999). Coping skills training reduced haemoglobin A1c and improved self efficacy in youths with diabetes [commentary on Grey M, Boland EA, Davidson M, et al. Coping skills training for youths with diabetes on intensive therapy. Appl Nurs Res 1999 Feb;12(1):3–12]. Evid Based Nurs.
90 Wroe C. (2003). Diabetes UK 2003 Professional Conference. Practical Diabetes International.
91 Wroe CD, Baksi AK. (1995). Diabetes care: A challenge for the 21st century. The 15th International Diabetes Federation Congress. 6–11 November, 1994, Kobe, Japan. Practical Diabetes International.
92 Wysocki T, Miller KM, Greco P, et al. (1999). Behavior therapy for families of adolescents with diabetes: effects on directly observed family interactions. Behav Ther.
93 Yeager S. (2002). Weekend Programming: The Barton Center for Diabetes Education. Camping Magazine.

## Population

For all questions in this review, the populations had to be children (≤18 years) with type 1 diabetes mellitus and their families. The following 108 studies did not have the relevant population.

### References

1 Effects of intensive diabetes therapy on neuropsychological function in adults in the Diabetes Control and Complications Trial. Ann Intern Med 1996;124(4):379–88.
2 Influence of intensive diabetes treatment on quality-of-life outcomes in the diabetes control and complications trial. Diabetes Care 1996;19(3):195–203.
3 Summer diabetes programs a healthy hit. Tribal College Journal 2003;15(2):23–6.
4 Ahring KK, Ahring JP, Joyce C, et al. (1992). Telephone modem access improves diabetes control in those with insulin-requiring diabetes. Diabetes Care.
5 Albisser AM, Harris RI, Sakkal S, et al. (1996). Diabetes intervention in the information age. Med Inform (Lond).
6 Allanach EJ, Allanach BC. (1984). Diabetes teaching follow-up compliance: a quality assurance evaluation. Mil Med.
7 Aoki N, Ohta S, Masuda H, et al. (2004). Edutainment tools for initial education of type-1 diabetes mellitus: initial diabetes education with fun. Medinfo.
8 Argo JK, Singh RH, Ostapchenko G. (1983). A. Competency based diabetes diet program. Diabetes Educ.
9 Bahru Y, Abdulkadir J. (1993). Assessment of diabetes education in the teaching hospital, Addis Ababa, Ethiopia. Diabet Med.
10 Baker AM, Lafata JE, Ward RE, et al. (2001). A Web-based diabetes care management support system. Jt Comm J Qual Improv.
11 Beeney LJ, Dunn SM. (1990). Knowledge improvement and metabolic control in diabetes education: approaching the limits?. Patient Educ Couns.
12 Borssen B, Bergenheim T, Lithner F. (1996). Preventive treatment of foot deformities in Type 1 diabetic patients aged 15–50 years—an epidemiological and prospective study. J Intern Med.
13 Brown S, Hanis CL. (1995). A community-based, culturally sensitive education and group-support intervention for Mexican Americans with NIDDM: a pilot study of efficacy. Diabetes Educ.
14 Carter IR, Nash C, Ridgway A. (2002). On any Saturday—a practical model for diabetes education. J Natl Med Assoc.
15 Curtis S, Hall J, Robertson A. (2000). The provision of diabetes information collections in public libraries as an adjunct to patient centre education: a preliminary study. Practical Diabetes International.
16 De KI, Reeser HM, Oostdijk W, et al. (2005). Randomized trial of a color-coded slide rule in children with diabetes. Diabetes Care.
17 Garrard J, Jones JO, Mullen L, et al. (1988). Differences in patient knowledge about diabetes as a function of type of primary care physician. Diabetes Educ.
18 Garrard J, Mullen L, Joynes JO, et al. (1990). Clinical evaluation of the impact of a patient education program. Diabetes Educ.
19 Garrett AM. The educator-learner relationship and learning in diabetes [masters theses]. Kingston, ON: Queen's University at Kingston; 1997.
20 Gerber BS, Solomon MC, Shaffer TL, et al. Evaluation of an internet diabetes self-management training program for adolescents and young adults. Diabetes Technol Ther 2007;9(1):60–7, 2007 Feb.
21 Germer S, Campbell IW, Smith AW, et al. (1986). Do diabetics remember all they have been taught? A survey of knowledge of insulin-dependent diabetics. Diabet Med.
22 Gillis B, Shannon B, Smiciklas WH, et al. (1986). DOTS: a new tool for teaching the diabetic food exchange system. J Am Diet Assoc.
23 Haisch J, Remmele W. (2000). [Effectiveness and efficiency of ambulatory diabetes education programs. A comparison of specialty practice and general practice]. Dtsch Med Wochenschr.
24 Hamalainen H, Ronnemaa T, Toikka T, et al. (1998). Long-term effects of one year of intensified podiatric activities on foot-care knowledge and self-care habits in patients with diabetes. Diabetes Educ.
25 Hanestad BR, Albrektsen G. (1993). The effects of participation in a support group on self-assessed quality of life in people with insulin-dependent diabetes mellitus. Diabetes Res Clin Pract.
26 Hansen HL. Health outcomes of a diabetes supply and diabetes self-management education program in an at-risk population [dissertation]. Denton, TX: Texas Woman's University; 2000.
27 Hasler TD, Fisher BM, MacIntyre PD, et al. (2000). Exercise consultation and physical activity in patients with type 1 diabetes. Practical Diabetes International.
28 Heggie J. (2002). Effectiveness of diabetes eye health education during retinal screening. Diabetes Primary Care.
29 Hernandez C, Williamson KM. Evaluation of a self-awareness education session for youth education with type 1 diabetes. Pediatr Nurs 30(6):459–64.
30 Holcomb JD, Kingery PM, Sherman LD, et al. (1999). Evaluation of a diabetes education program for fifth-grade students. J Health Educ.
31 Holstein BE, Vesterdal JH, Sestoft L. (1986). Illness-behaviour attitude and knowledge in newly diagnosed diabetics. Dan Med Bull.
32 Hoskings PH, Alford J, Fowler P, et al. Outpatient stabilisation program. An innovative approach in the management of diabetes in a large teaching hospital. Aust Clin Rev 1984;(15):8–11.
33 Houston JM, Martin M, Williams JE, et al. (2006). The Annual African American Conference on Diabetes: evolving program evaluation with evolving program implementation [abstract]. Prev Chronic Dis.
34 Howells L, Wilson AC, Skinner TC, et al. (2002). A randomized control trial of the effect of negotiated telephone support on glycaemic control in young people with Type 1 diabetes. Diabet Med.
35 Howorka K, Pumprla J, Wagner ND, et al. (2000). Empowering diabetes out-patients with structured education: short-term and long-term effects of functional insulin treatment on perceived control over diabetes. J Psychosom Res.
36 Hurley AC, Shea C. (1992). Self-efficacy: strategy for enhancing diabetes self-care. Diabetes Educ.
37 Iafusco D, Ingenito N, Prisco F. (2000). The chatline as a communication and educational tool in adolescents with insulin-dependent diabetes: preliminary observations. Diabetes Care.
38 Jayasuriya R, Griffiths R, Cheung J. (2000). Outcome assessment of a community based model of general practitioner care diabetes patients. Practical Diabetes International.
39 Jenhani M, Gaha K, Nabouli R, et al. (2005). Effectiveness of patient education on glycemic control in insulin treated patients in general practice. Diabetes Metab.
40 Jennings PE, Morgan HC, Barnett AH. (1987). Improved diabetes control and knowledge during a diabetes self-help group. Diabetes Educ.
41 Jimenez FJ, Monsanto H. (2001). Screening, monitoring, and educating patients with diabetes in an independent community pharmacy in Puerto Rico. P R Health Sci J.
42 Kalergis M. The evaluation of three treatment strategies in subjects with type I diabetes mellitus undergoing intensive diabetes management: metabolic, psycho-social and educational implications [master's thesis]. Montreal, PQ: McGill University; 1996.
43 Kelly J, Crowe P, Shearer M. The Good Life Club project: telephone coaching for chronic disease self management. Aust Fam Physician 2005 Jan–Feb(1/2):31–4.
44 King HB, Schulz C, Watts J. (1996). A First Nations community-based diabetes education program: the Nuu-chah-nulth experience. Can J Diabetes Care.
45 Koev D, Kozlovski P, Tankova T, et al. (2001). Diabetes Education Program in Bulgaria. Patient Educ Couns.
46 Koproski J, Pretto Z, Poretsky L. (1997). Effects of an intervention by a diabetes team in hospitalized patients with diabetes. Diabetes Care.
47 Kronz KK, Hibbard R, Marrero DG, et al. (1989). Management of diabetes in pediatric resident continuity clinics. Am J Dis Child.
48 Kulkarni K, Castle G, Gregory R, et al. (1998). Nutrition Practice Guidelines for Type 1 Diabetes Mellitus positively affect dietitian practices and patient outcomes. The Diabetes Care and Education Dietetic Practice Group. J Am Diet Assoc.
49 Leslie PJ, Drummond N, Caiger P, et al. (1989). HbA1 self-recording in the management of diabetes mellitus. J Intern Med.
50 Lester FT, Demissie Y, Negash A. (1990). Insulin injection technique can be taught without hospitalization. Ethiop Med J.
51 Liesenfeld B, Renner R, Neese M, et al. (2000). Telemedical care reduces hypoglycemias and improves glycemic control in children and adolescents with type 1 diabetes. Diabetes Technol Ther.
52 Lo R, Lo B, Wells E, et al. (1996). The development and evaluation of a computer-aided diabetes education program. Aust J Adv Nurs.
53 Malasanos TH, Burlingame JA, Sloyer P, et al. (2004). Decreased hospitalization and emergency care during first 2 years of telemedicine program for children with diabetes [abstract]. Diabetes.
54 Malik R, Horwitz DL, Smyth Staruch K. (1987). Energy metabolism in diabetes: computer-assisted instruction for persons with diabetes. Diabetes Educ.
55 Mannucci E, Pala L, Rotella CM. (2005). Long-term interactive group education for type 1 diabetic patients. Acta Diabetol.
56 Mannucci E, Ricca V, Mezzani B, et al. (1995). Eating attitude and behavior in IDDM patients: a case-controlled study. Diabetes Care.
57 Massaro E, Claiborne N. (2001). Professional development. Effective strategies for reaching high-risk minorities with diabetes. Diabetes Educ.
58 Matam P, Kumaraiah V, Munichoodappa C, et al. (2000). Behavioural intervention in the management of compliance in young type-I diabetics. J Assoc Physicians India.
59 Matsuoka K, Horiuchi A, Kitamura S, et al. (1984). Who teaches the patient? A team approach. Diabetes Educ.
60 Matteucci E, Giampietro O. (2003). Closing the gap between literature and practice: evaluation of a teaching programme (in the absence of a structured treatment) on both Type 1 and Type 2 diabetes. Diabetes Nutr Metab.
61 McGee K, Mullenix TA, Joachim D, et al. (2002). The impact of an educational intervention on caregiver knowledge of diabetes mellitus in a population-adjusted clinical epidemiology program [abstract]. Pharmacotherapy.
62 Mcgill TL. An outcomes study of diabetes education [dissertation]. Reno, NV: University of Nevada; 2000.
63 Muhlhauser I, Bruckner I, Berger M, et al. (1987). Evaluation of an intensified insulin treatment and teaching programme as routine management of type 1 (insulin-dependent) diabetes. The Bucharest-Dusseldorf Study. Diabetologia.
64 Muhlhauser I, Jorgens V, Berger M, et al. (1983). Bicentric evaluation of a teaching and treatment programme for type 1 (insulin-dependent) diabetic patients: improvement of metabolic control and other measures of diabetes care for up to 22 months. Diabetologia.
65 Neumann L, Weitzman S, Gross J. (1989). Improved knowledge of diabetic patients through education of primary care staff. Health Policy.
66 Nusbaum NJ, Gant L. (1999). Focused nutritional intervention in the home care setting. Home Health Care Management & Practice.
67 O'Connor PJ, Crabtree BF, Abourizk NN. (1992). Longitudinal study of a diabetes education and care intervention: predictors of improved glycemic control. J Am Board Fam Pract.
68 Pagliari C, Clark D, Hunter K, et al. (2003). DARTS 2000 online diabetes management system: formative evaluation in clinical practice. J Eval Clin Pract.
69 Piaggesi A, Giampietro O, Picaro L, et al. (1989). Individual teaching as a first-step intervention for the education of diabetic subjects. Acta Diabetol Lat.
70 Pichert JW, Hanson SL, Pechmann C. Modifying dietitians' use of patient time. Diabetes Educ 1984;10(1):43–6,72.
71 Pichert JW, Hanson SL, Pechmann C. (1985). A system for assessing use of patients' time. Eval Health Prof.
72 Pieber TR, Brunner GA, Schnedl WJ, et al. (1995). Evaluation of a structured outpatient group education program for intensive insulin therapy. Diabetes Care.
73 Ramalho A, de Lourdes C, Lima M, et al. (2006). The effect of resistance versus aerobic training on metabolic control in patients with type-1 diabetes mellitus. Diabetes Res Clin Pract.
74 Rettig BA, Shrauger DG, Recker RR, et al. (1986). A randomized study of the effects of a home diabetes education program. Diabetes Care.
75 Rowe AB. The use of biofeedback assisted relaxation training as a method to improve blood glucose control in type i diabetics [dissertation]. Cincinnati, OH: Union for Experimenting Colleges and Universities; 1986.
76 Schiel R, Muller U, Ulbrich S. (1997). Long-term efficacy of a 5-day structured teaching and treatment programme for intensified conventional insulin therapy and risk for severe hypoglycemia. Diabetes Res Clin Pract.
77 Sheard CM. (1984). How effective is our advice to diabetics? A preliminary evaluation. Hum Nutr Appl Nutr.
78 Sidorov J, Gabbay R, Harris R, et al. (2000). Disease management for diabetes mellitus: impact on hemoglobin A1c. Am J Manag Care.
79 Simmons D. (1992). Diabetes self help facilitated by local diabetes research: The Coventry Asian Diabetes Support Group. Diabet Med.
80 Simmons D, Gamble GD, Foote S, et al. (2004). The New Zealand Diabetes Passport Study: a randomized controlled trial of the impact of a diabetes passport on risk factors for diabetes-related complications. Diabet Med.
81 Smith KE, Dickerson P, Saylor CF, et al. (1989). Issues of managing diabetes in children and adolescents: a multifamily group approach. Child Health Care.
82 Spiess K, Sachs G, Pietschmann P, et al. (1995). A program to reduce onset distress in unselected type-I diabetic-patients—effects on psychological variables and metabolic control. Eur J Endocrinol.
83 Starostina EG, Antsiferov M, Galstyan GR, et al. (1994). Effectiveness and cost-benefit analysis of intensive treatment and teaching programmes for Type 1 (insulin-dependent) diabetes mellitus in Moscow-blood glucose versus urine glucose self-monitoring. Diabetologia.
84 Stegmayer P, Lovrien FC, Smith M, et al. (1988). Designing a diabetes nutrition education program for a Native American community. Diabetes Educ.
85 Sullivan ED, Joseph DH. (2000). University/community partnership to improve the lives of people with diabetes. Practical Diabetes International.
86 Sullivan ED, Joseph DH. (2000). University/community partnership to improve the lives of people with diabetes. Practical Diabetes International.
87 Sutherland JE, Hoehns JD, O'Donnell B, et al. (2001). Diabetes management quality improvement in a family practice residency program. J Am Board Fam Pract.
88 Temple AJS. The effects of diabetes self-management education on diabetes self-care, diabetes self-efficacy, and psychological adjustment to diabetes [dissertation]. New Orleans, LA: Louisiana State University Health Sciences Center School of Nursing; 2003.
89 Terent A, Hagfall O, Cederholm U. (1985). The effect of education and self-monitoring of blood glucose on glycosylated hemoglobin in type I diabetes. A controlled 18-month trial in a representative population. Acta Med Scand.
90 The Diabetes Control and Complications Trial. Effect of intensive diabetes management on macrovascular events and risk factors in the Diabetes Control and Complications Trial. Am J Cardiol 1995;75(14):894–903.
91 The Diabetes Control and Complications Trial Research Group. (1998). Effect of intensive therapy on residual beta-cell function in patients with type 1 diabetes in the diabetes control and complications trial. A randomized, controlled trial. Ann Intern Med.
92 The Diabetes Control and Complications Trial Research Group. (1997). Hypoglycemia in the Diabetes Control and Complications Trial. Diabetes.
93 Thorell B, Olsson L, Svardsudd K. (1994). Implementation of a structured care programme for diabetes mellitus in a defined population in mid-Sweden. Diabet Med.
94 Toth EL, James I. (1992). Description of a diabetes support group: lessons for diabetes caregivers. Diabet Med.
95 Turnin MC, Bolzonella PC, Dumoulin S, et al. (1995). [Multicenter evaluation of the Nutri-Expert Telematic System in diabetic patients]. Diabete Metab.
96 Uchigata Y, Asao K, Matsushima M, et al. (2004). Impact on mortality and incidence of end-stage renal disease of education and treatment at a diabetes center among patients with type 1 diabetes: comparison of two subgroups in the Japanese DERI cohort. J Diabetes Complications.
97 Uddin I, Ahmad TJ, Kurkuman AR, et al. (2001). Diabetes education: its effects on glycemic control. Ann Saudi Med.
98 Verlato G, Muggeo M, Bonora E, et al. (1996). Attending the diabetes center is associated with increased 5-year survival probability of diabetic patients: The Verona Diabetes Study. Diabetes Care.
99 Viinamaki H, Niskanen L. (1991). Psychotherapy in patients with poorly controlled type 1 (insulin-dependent) diabetes. Psychother Psychosom.
100 Wdowik MJ, Kendall P, Harris M, et al. (2000). Development and evaluation of an intervention program: “Control on Campus”. Diabetes Educ.
101 Webb KL, Dobson AJ, O'Connell DL, et al. (1984). Dietary compliance among insulin-dependent diabetics. J Chronic Dis.
102 Werdier D, Jesdinsky HJ, Helmich P. (1984). A randomized, controlled study on the effect of diabetes counseling in the offices of 12 general practitioners. Rev Epidemiol Sante Publique.
103 Whitlock WL, Brown A, Moore K, et al. (2000). Telemedicine improved diabetic management. Mil Med.
104 Wilson E, Wardle EV, Chandel P, et al. (1993). Diabetes education: an Asian perspective. Diabet Med.
105 Wolever TM, Hamad S, Chiasson JL, et al. (1999). Day-to-day consistency in amount and source of carbohydrate associated with improved blood glucose control in type 1 diabetes. J Am Coll Nutr.
106 Yan C, Miao FY. (1989). Summer camps for diabetic children in Beijing of China. Indian J Pediatr.
107 Yong A, Power E, Gill G. (2002). Improving glycaemic control of insulin-treated diabetic patients—a structured audit of specialist nurse intervention. J Clin Nurs.
108 Zador I, Meyer LJ, Scheets DR, et al. (2006). Hemoglobin A1c in obese children and adolescents who participated in a weight management program. Acta Paediatr.

## Intervention

For key questions pertaining to diabetes education programs, at least one of the following topics had to be included in the intervention: 1) diabetes disease process and treatment options; 2) nutritional management; 3) physical activity; 4) monitoring blood glucose, urine ketones (when appropriate), and using the results to improve control; 5) utilizing medications; 6) preventing, detecting, and treating acute complications; 7) preventing (through risk reduction behaviour), detecting, and treating chronic complications; 8) goal setting to promote health and problem solving for daily living; and 9) psychosocial adjustment. The control/comparison group could be no treatment or standard care. The following 13 studies did not meet the inclusion criteria.

### References

1 Achenbach P, Warncke K, Reiter J, et al. (2006). Type 1 diabetes risk assessment: improvement by follow-up measurements in young islet autoantibody-positive relatives. Diabetologia.
2 Campaigne BN, Gilliam TB, Spencer ML, et al. (1984). Effects of a physical activity program on metabolic control and cardiovascular fitness in children with insulin-dependent diabetes mellitus. Diabetes Care.
3 DiMeglio L, Pottorff TM, Boyd SR, et al. (2004). A randomized, controlled study of insulin pump therapy in diabetic preschoolers. J Pediatr.
4 Eastman BG, Johnson SB, Silverstein J, et al. (1983). Understanding of hypo- and hyperglycemia by youngsters with diabetes and their parents. J Pediatr Psychol.
5 Lowes L. Specialist nursing. Evaluation of a paediatric diabetes specialist nurse post. Br J Nurs 1997;6(11):625–6, 628–33.
6 Mortweet S, Robinson J, Howard C. (2000). What do you know? The impact of information on the management of type-1 diabetes in children [abstract]. Diabetes.
7 Oliver CM, Johnston CC, Winkler SJ. Problem-solving and adjustment to life with diabetes among adolescents with insulin-dependent diabetes mellitus. In: King K, Prodrick E, Bauer B, eds. Proceedings of the 10th National Research Conference: Nursing Research: Science for Quality Care; 1985 April; Toronto, Ontario. Toronto, ON: University of Toronto; 1986. p. 329–32.
8 Rami B, Popow C, Horn W, et al. (2006). Telemedical support to improve glycemic control in adolescents with type 1 diabetes mellitus. Eur J Pediatr.
9 Stratton R, Wilson DP, Endres RK, et al. (1987). Improved glycemic control after supervised 8-wk exercise program in insulin-dependent diabetic adolescents. Diabetes Care.
10 Vanelli M, Chiarelli F, Chiari G, et al. (1999). Metabolic control in children and adolescents with diabetes: experience of two Italian regional centers. J Pediatr Endocrinol Metab.
11 Villagra VG, Ahmed T. (2004). Effectiveness of a disease management program for patients with diabetes. Health Aff (Millwood).
12 Whittemore RU, Tamborlane RD, William V, et al. (2003). Quality of life in school-aged children with type 1 diabetes on intensive treatment and their parents. Diabetes Educ.
13 Wolters C, Yu SL, Hagen JW, et al. (1996). Short-term memory and strategy use in children with insulin-dependent diabetes mellitus. J Consult Clin Psychol.

## Ongoing

The following three studies were not yet completed and no outcome data were available.

### References

1 Muir AB, Geffken GR, McKnight M, et al. (2004). Feasibility of computer assisted training (CAT) in families of newly diagnosed type I diabetes [abstract]. Diabetes.
2 Streisand R, Hilliard M, Mednick L, et al. Preliminary results of an RCT to prevent nonadherence among preadolescents with T1 diabetes [web page]. Available at: http://professional.diabetes.org/Abstracts_Display.aspx?TYP=1&CID=48746. Accessed 2007.
3 Streisand R, Mednick L. (2006). Development of the diabetes education, counseling, information delivery and evaluation (DECIDE) program: a health promotion intervention for preadolescents with type 1 diabetes. J Clin Psychol Med Settings.

## Outcome

Studies were included if they reported the following outcomes: metabolic control (as measured by HbA1c), hospitalization, ED utilization, short term complications (e.g., diabetic ketoacidosis, episodes of hypoglycemia), long term complications (retinal, renal, cardiovascular, neurological), quality of life; school attendance and performance, self confidence in ability to cope with disease, or psychosocial outcomes. The following 14 studies did not report any of the appropriate outcomes or reported lifestyle outcomes (e.g., smoking, use of recreational drugs, participation in extracurricular activities).

### References

1 Aoki N, Ohta S, Okada T, et al. (2005). INSULOT: a cellular phone-based edutainment learning tool for children with type 1 diabetes. Diabetes Care.
2 Can G, Okten A, Kaya G. (2001). The effects of the local camps on children with type I diabetes mellitus. Annals of Medical Sciences.
3 Daley B. (1985). The use of activities in the approach to non-compliance in the treatment of juvenile diabetes. Int J Adolesc Med Health.
4 Deris-Atassi S. A program design for Hispanic caregivers of children with newly diagnosed type 1 diabetes mellitus [dissertation]. Miami, FL: Carlos Albizu University; 2002.
5 Krause ER. Influence of self-monitoring and visual discrimination training on children's accuracy in blood glucose monitoring (diabetes, teaching straegies, error analysis) [dissertation]. Denver, CO: University of Denver; 1984.
6 Lavalle F, De la Garza N, Martinez I, et al. (1998). Forgetfulness curve, exposure to an educational program for youths with type 1 diabetes [abstract]. Diabetes.
7 Malasanos TH, Burlingame JB, Youngblade L, et al. (2005). Improved access to subspecialist diabetes care by telemedicine: cost savings and care measures in the first two years of the FITE diabetes project. J Telemed Telecare.
8 Nurick M, Johnson SB. (1991). Enhancing blood glucose awareness in adolescents and young adults with IDDM. Diabetes Care.
9 Razeghi S, Renner C, Schafer S, et al. (1998). Project D: computer-mediated communication as a tool for self-help in children and adolescents with diabetes. Diabetes Educ.
10 Salvatoni A, Pompili V, Biasoli R, et al. (2003). [“Governare il diabete” (“to steer diabetes”): a new proposal for diabetic camps]. Acta Biomed Ateneo Parmense.
11 Silverstein JH, Bandyopadhyay R. (1995). Camping with a friend. Helping adolescents cope with diabetes. J Fla Med Assoc.
12 Solowiejczyk J. (2004). The family approach to diabetes management: theory into practice toward the development of a new paradigm. Diabetes Spectrum.
13 Wangberg SC, Arsand E, Andersson N. (2006). Diabetes education via mobile text messaging. J Telemed Telecare.
14 Waszak LC. The effects of parent education on adherence and metabolic control of children with insulin-dependent diabetes mellitus [dissertation]. Pittsburgh, PA: University of Pittsburgh; 1987.

## Reporting

The following 37 studies were excluded because they did not provide a description of the intervention that was sufficient to reproduce it, or they did not provide measurable data for outcomes relevant to this review.

### References

1 Ahern J, Ramchandani N, Cooper J, et al. (2000). Using a primary nurse manager to implement DCCT recommendations in a large pediatric program. Diabetes Educ.
2 Arraya G, Trave D, Benavent M. (1998). [The influence of education for metabolic control in infant-youth diabetes patients]. Revista ROL de Enfermeria.
3 Auslander WF. (1993). Brief family interventions to improve family communication and co-operation regarding diabetes management. Diabetes Spectrum.
4 Basso R. (1991). A structured-fantasy group experience in a children's diabetic education program. Patient Educ Couns.
5 Codner DE, Mericq GV, Garcia BH, et al. (2003). Results of a multidisciplinary and intensified treatment program for type 1 diabetes mellitus in a Chilean public hospital. Rev Med Chil.
6 Dammacco F, Torelli C, Frezza E, et al. (1989). Computer based instruction of diabetic children and adolescents. Techniques and results. J Endocrinol Invest.
7 Delamater AM, Smith J, Kurtz SM, et al. (1988). Dietary skills and adherence in children with type I diabetes mellitus. Diabetes Educ.
8 Follansbee DJ, Lagreca AM, Citrin WS. (1983). Coping skills training for adolescents with diabetes [abstract]. Diabetes.
9 Hansson K, Ryden O, Johnsson P. (1994). Parent-rated family climate: a concomitant to metabolic control in juvenile IDDM. Fam Syst Med.
10 Hardway D, Weatherly KS, Bonheur B. (1993). Diabetes education on wheels. J Nurs Staff Dev.
11 Hedbrant J, Ludvigsson J. (1995). Use of computer simulator training in the education of diabetic teenagers. Practical Diabetes International.
12 Heidgerken AD, Adkins J, Storch E, et al. (2006). Telehealth intervention for adolescents with type 1 diabetes. J Pediatr.
13 Hunter HL, Rosnov DL, Koontz D, et al. (2006). Camping programs for children with chronic illness as a modality for recreation, treatment, and evaluation: an example of a mission-based program evaluation of a diabetes camp. J Clin Psychol Med Settings.
14 Jones E, Murphy LG. (2002). The efficacy of intensive individual play therapy for chronically ill children. International Journal of Play Therapy.
15 Kaufman FR, Costin G, Roe TF, et al. (1986). The efficacy of a residential-treatment program (RTP) for childhood diabetes-mellitus (JDM) [abstract]. Diabetes.
16 Keeter EL, Linehan MS. (1993). Affecting children's attitudes toward diabetes through camp. Nurse Pract.
17 Kieren DK, Hurlbut NL, Looney T, et al. Designing a family problem solving training program with an adolescent diabetic. Paper presented at the Conference of the National Council on Family Relations; 1987 November 3–7; Atlanta, GA.
18 Knight KM, Bundy C, Morris R, et al. (2003). The effects of group motivational interviewing and externalizing conversations for adolescents with type-1 diabetes. Psychol Health Med.
19 Koplatadze K, Koplatadze M, Kacharava L, et al. (2003). Diabetes camps: an international experience. Mo Med.
20 Kurmacheva N, Svinaryov MY, Kireev R, et al. (1999). Self-control teaching and its influence on insulin-dependent diabetes mellitus complications incidence in children [abstract]. Diabetes Nutr Metab.
21 Lorini R, Ciriaco O, Salvatoni A, et al. (1990). The influence of dietary education in diabetic children. Diabetes Res Clin Pract.
22 MacDonald MJ, Kerouz N, Hayek R, et al. (1993). Early referral of children with IDDM to a specialized program correlates with better long-term metabolic control. Diabetes Care.
23 Malasanos TH , Patel BD, Stein JM, et al. FITE Diabetes: improved access to sub-specialist care by telemedicine; no detrimental effect on A1c over 3 years [web page]. 2006; Available at: http://scientificsessions.diabetes.org/Abstracts/index.cfm?fuseaction=Locator.SearchAbstracts. Accessed 2007.
24 Maryniuk MD, Kauwell GPA, Thomas RG. (1986). A test of instructional approaches designed to influence food selection...children and adolescents with diabetes. Diabetes Educ.
25 McKelvey J, Borgersen M. (1990). Family development and the use of diabetes groups: experience with a model approach. Patient Educ Couns.
26 Misuraca A, Di Gennaro M, Lioniello M, et al. (1996). Summer camps for diabetic children: an experience in Campania, Italy. Diabetes Res Clin Pract.
27 Nordfeldt S, Ludvigsson J. (1999). Prevention of severe hypoglycaemia in type 1 diabetes children. A prospective intervention study 1995-98 [abstract]. Diabetologia.
28 Opipari AL, Kichler J, Fredericks E, et al. (2004). The Kids Project: medical and psychosocial outcomes of an intervention to kick in diabetes support for economically disadvantaged adolescents with type 1 diabetes mellitus [abstract]. Pediatr Res.
29 Scharf LS. Efficacy of diabetes camp in improving psychological adjustment of adolescents [dissertation]. Detroit, MI: Wayne State University; 1985.
30 Shaltout A, Qabazard M, Khawari M, et al. (1995). Towards improving care for children with diabetes in Kuwait. Int J Health Care Qual Assur.
31 Spevack M, Johnson S, Bennett R, et al. The effect of diabetes summer camp on adherence behaviors and glycemic control. In: Johnson JH, Johnson SB, eds. In: Advances in child health psychology. Gainesville, FL: J Hillis Miller Health Science Center; 1991. p. 285–92.
32 Stinchfield PA. Evaluation of an education program for Type I diabetics [dissertation]. Salt Lake City, UT: University of Utah College of Nursing; 1987.
33 Strickland BR. (1983). Management of diabetic children by behavior-modification and blood-glucose monitoring [abstract]. Drug Intell Clin Pharm.
34 von Sengbusch S, Wagner V, Muller GE, et al. (2005). [Mobile Diabetes Education Programme Schleswig-Holstein (Mdsh). A new training concept and model for diabetes care for children and adolescents with type 1 diabetes and its effects on the family burden]. Kindheit Und Entwicklung.
35 Weist MD, Finney JW, Barnard MU, et al. (1993). Empirical selection of psychosocial treatment targets for children and adolescents with diabetes. J Pediatr Psychol.
36 Zhou YH, Lin CL, Zhou M, et al. (2005). [Interventional effect of cognitive education on the quality of life in 227 patients with diabetes mellitus from 4 hospitals in Meizhou city]. Chinese Journal of Clinical Rehabilitation [Zhongguo Linchuang Kangfu].
37 Zimmerman E, Carter MC, Sears JH, et al. (1987). Diabetic camping: effect on knowledge, attitude, and self-concept. Issues Compr Pediatr Nurs.

## Small Sample Size (n≤10)

The following nine studies were excluded because there were ≤ 10 participants enrolled in the study.

### References

1 Albrecht SJ. Increasing blood glucose monitoring in adolescents with type 1 diabetes: effects of a prompt [dissertation]. Kalamazoo, MI: Western Michigan University; 2005.
2 Hains A, Davies WH, Parton E, et al. (2001). Brief report: a cognitive behavioral intervention for distressed adolescents with type I diabetes. J Pediatr Psychol.
3 Hains AA, Davies W, Hobart P, et al. (2001). A cognitive behavioral intervention for distressed adolescents with Type I diabetes. J Pediatr Psychol.
4 Lasecki KL. Normalizing blood glucose levels in children with type I diabetes: mystery motivators used within the context of behavioral consultation models [dissertation]. Salt Lake City, UT: University of Utah; 2000.
5 Marrero DG, Fremion AS, Golden MP. (1988). Improving compliance with exercise in adolescents with insulin-dependent diabetes mellitus: results of a self-motivated home exercise program. Pediatrics.
6 Oksol EM. A treatment development study: a preliminary analysis of a new treatment for parents of diabetic children in poor glycemic control [dissertation]. Reno, NV: University of Nevada; 2004.
7 Rose MI, Firestone P, Heick HM, et al. (1983). The effects of anxiety management training on the control of juvenile diabetes mellitus. J Behav Med.
8 Silverman AH. Increasing regimen adherence in adolescents with type I diabetes [dissertation]. Milwaukee, WI: University of Wisconsin; 2002.
9 Silverman AH, Hains A, Davies WH, et al. (2003). A cognitive behavioral adherence intervention for adolescents with type 1 diabetes. J Clin Psychol Med Settings.

## Studies Unavailable

The following 46 studies were requested through our interlibrary loan service but did not arrive within the 7-month cut-off that we established for article retrieval.

### References

1 Diabetes program teaches kids to be case managers. Dis State Manag 1997;3(11):138–40.
2 Ambrosino J, Fennie K, Hendrickson K, et al. (2005). Coping skills training with parents of school-aged youth with type 1 diabetes (T1d) improves family functioning [abstract]. Diabetes.
3 Assaad-Khalil SH, El Siwy F, Kamel KF, et al. (2003). Impact of an educational video film: “The Jinn's Party” on the knowledge, practices and attitudes of school children and adolescents with type 1 diabetes and their parents. Diabetologia.
4 Bartus B, Hecker W. (1994). Age-adapted hypoglycemia awareness training for children and adolescents with insulin-dependent diabetes-mellitus (Iddm) [abstract]. Diabetologia.
5 Bellando BJ. Changes in short-term and long-term control of diabetes after participation in Blood Glucose Awareness Training [dissertation]. Lubbock, TX: Texas Tech University; 1989.
6 British Diabetic Association. (1995). Education and Professional Care Section and Medical and Scientific Section 1995 Oct 4–6; Harrogate. Diabet Med.
7 British Diabetic Association. (1994). Education and Professional Care section annual conference 1994 Sep 7–9 and Medical and Scientific Section autumn meeting 1994 Sep 8–9. Lancaster.
8 British Dietetic Association. Conference of the Community Nutrition Group and Health Education Authority; 1991 March; London. In: Hurren CA, Black AE, eds. The food network: achieving a healthy diet by the year 2000. London: Smith-Gordon; 1991.
9 Campaigne B. The effects of a physical activity program on children ages 5 to 11 years with insulin-dependent diabetes mellitus [dissertation]. Ann Arbor, MI: University of Michigan; 1982.
10 Charron Prochownik D, Becker D, Sereika S, et al. (2001). The impact of a newly developed CD-ROM reproductive health education program on teens with diabetes [abstract]. Diabetes.
11 Clawson E, Kade D, Dickens M. (1996). Efficacy of a rehabilitation program for children and adolescents who are chronically noncompliant with diabetes management [abstract]. Diabetes.
12 Cook S, McNabb WL. (1999). Problem-solving program for adolescents with diabetes: choices [abstract]. Diabetes.
13 Dammacco F, Frezza E, Torelli C, et al. (1984). Computerized mastery learning instruction of diabetic children [abstract]. Diabetologia.
14 Etzwiler DD. Education and participation of patients and their families. Pediatr Ann 1983;12(9):638–40,642.
15 Fekete D, Guare J, Marrero D, et al. (1997). Self-management of “off diet” food intake by adolescents and young adults with insulin-dependent diabetes mellitus (Iddm). Diabetes.
16 Follansbee DJ. Coping skills training for adolescents with insulin dependent diabetes mellitus [dissertation]. Miami, FL: University of Miami; 1984.
17 Franzen I, Ludvigsson J. (1997). Specific instructions gave reduction of lipomas and improved metabolic control in diabetic children [abstract]. Diabetologia.
18 Furman SG. The effect of assertiveness training on locus of control and metabolic control of adolescents with diabetes mellitus [dissertation]. Ft. Lauderdale, FL: Nova University School of Psychology; 1983.
19 George C. Video in pediatric patient education: the role of formal features in the relationship of intervention, knowledge, and anxiety [dissertation]. Austin, TX: University of Texas at Austin; 1991.
20 Gordeladze MR, Marinashvili N. (2002). Differential diabetes education program for children and adolescents its role and results [abstract]. Diabetologia.
21 Halvorson M, Kaufman FR, Carpenter S. (1996). Evaluation of a comprehensive childhood diabetes program with intensive management [abstract]. Diabetes.
22 Halvorson MJ, Kaufman FR, Engilman R. (1999). Comparison of a diabetes Cd-Rom program, diabetes video game and diabetes kids class in diabetes management and knowledge acquisiton in children ages 5–10 with type 1 diabetes [abstract]. Diabetes.
23 Harris R. (2003). Diabetic teddies help children to learn. ACCNS Journal for Community Nurses.
24 Hayes JR. Controlling glucose levels of adolescents with diabetes through the use of a voice processing system [dissertation]. Columbus, OH: Ohio State University; 1996.
25 Howells L. (2001). Telephone support to improve outcomes in young people. Journal of Diabetes Nursing.
26 Huttunen NP, Lankela SL, Knip M, et al. (1987). Effect of a once-a-week training-program on physical-fitness and metabolic control of diabetes in children with type-1 diabetes [abstract]. Acta Endocrinol (Copenh).
27 International Society for Pediatric and Adolescent Diabetes. 6th ISPAD Workshop: controversial issues in childhood and adolescent diabetes mellitus; 1997 April; Garda, Italy. In: Journal of Pediatric Endocrinology and Metabolism, Laron Z, Pinelli L. eds.; Tel Aviv, Israel: Freund Publishing House; 1998.
28 Kaufman V. The effect of educational and psychological programs on metabolic management and glycemic control in diabetes mellitus [dissertation]. San Diego, CA: California School of Professional Psychology—San Diego; 1987.
29 Levine BS, Anderson B, Butler D, et al. (2000). Care Ambassador (CA) intervention reduces costly adverse outcomes in youth with type 1 diabetes: a randomized, controlled trial [abstract]. Diabetes.
30 Marrero DG. Adjustment to misfortune: an intervention program to improve metabolic stability of insulin dependent diabetes mellitus in adolescents [dissertation]. Irvine, CA: University of California, Irvine; 1983.
31 Morimoto M, Fukumoto H, Kawabata E. (1997). Family education program for the hospitalized diabetic patients [abstract]. Diabetologia.
32 Murkin SA, Snyder GM, Pichert JW, et al. (1990). Anchored instruction enhances diabetes problem solving. Diabetes Care.
33 Okoawo IJ. Diabetic education and follow-up program: test of a model [dissertation]. Boston, MA: Boston University; 1984.
34 Opipari AL, Kichler J, Fredericks E, et al. (2005). Self-management intervention improves diabetes-related functioning in at-risk adolescents with type 1 diabetes [abstract]. Diabetes.
35 Pyorala E. (1997). Interaction strategies in dietary counselling of diabetic children [abstract]. Diabetologia.
36 Rajab A, Sadegian HA. (1997). The effect of home visiting program on blood glucose control in diabetic children in Iran [abstract]. Diabetologia.
37 Rami B, Schober E, Popow C, et al. (2004). Vie-Diab: telemedical support programme for adolescents with type 1 diabetes mellitus [abstract]. Diabetologia.
38 Schiel R, Perenthaler TJ, Kovar F, et al. (2005). Metabolic control and interactions with diabetes-related knowledge, motivational problems and technical devices in children and adolescents with type 1 diabetes mellitus—DIDOM, an intervention trial [abstract]. Diabetologia.
39 Sharma A. Diabetes prevention, education and treatment. International Journal of Diabetes 1994;2(3).
40 Sheldon AW. Computer-assisted diet and exercise training in the behavioral treatment of Type I diabetes [dissertation]. Miami, FL: University of Miami; 1996.
41 Silverman AH, Opipari ALC, Lang SW, et al. (2002). Intensive therapy and self-management training in pediatric medicaid patients with IDDM: perceptions of adolescents, parents and physicians [abstract]. Pediatr Res.
42 Sperlich SB. A diabetic camp: its implications for coping with juvenile diabetes mellitus [dissertation]. Washington, DC: The Catholic University of America; 1982.
43 Stinchfield PA. Evaluation of an education program for type 1 diabetes [dissertation]. Salt Lake City, Ut: University of Utah College of Nursing; 1987.
44 Szumowski EK. A family-oriented developmental and behavioral intervention to increase adherence by diabetic children to their treatment regimens [dissertation]. Pittsburgh, PA: University of Pittsburgh; 1991.
45 Tomasi F, Miselli V. (1989). Continuing and reinforcing patient education and metabolic control after a summer camp for diabetic children [abstract]. Diabetologia.
46 Wysocki T, Greco P, Harris M, et al. (1997). Behavior therapy for families of adolescents with Iddm: maintenance of treatment effects [abstract]. Diabetes.