# Appendix C. Sample Data Abstraction Forms

To see the Sample Data Abstraction Forms, please select the link below. This link will take you to a PDF version fo the forms.

Sample Data Abstraction Forms