# Appendix B. Exact Search Strings

## Table B1. MEDLINE^®^—OVID Version: rel10.4.1

Years/issue searched: 1950 to February Week 3 2007

Search date: March 4, 2007

Results: study design 4,219; no study design 6,615

1 exp Infant/
2 exp Child/
3 exp Adolescent/
4 exp Parents/
5 exp Family/
6 exp Caregivers/
7 infan$.mp.
8 (baby or babies).mp.
9 child$.mp.
10 toddler$.mp.
11 adolescen$.mp.
12 (young adj3 (person? or people or adult?)).mp.
13 (teen$ or teen ager?).mp.
14 youth?.mp.
15 juvenil$.mp.
16 pube$.mp.
17 parent$.mp.
18 famil$.mp.
19 (caregiv$ or care giv$ or care-giv$ or caretak$ or care tak$ or care-tak$ or carer?).mp.
20 or/1–19
21 Diabetes Mellitus/
22 Diabetes Mellitus, Type 1/
23 exp hypoglycemia/
24 ((type 1 or type I) adj (diabetes mellitus or DM)).mp.
25 ((diabetes mellitus or DM) adj (type 1 or type I)).mp.
26 diabet$.mp.
27 IDDM.mp.
28 DM.mp.
29 ((insulin-dependent or insulindependent) adj3 (diabetes mellitus or DM)).mp.
30 ((earl$ or juvenil$ or child$ or labil$ or keto$) adj3 (diabetes mellitus or DM)).mp.
31 ((autoimmun$ or auto-immun$ or auto immun$ or sudden onset) adj3 (diabetes mellitus or DM)).mp.
32 (insulin defic$ adj3 absolut$).mp.
33 hypoglyc?emi$.mp.
34 or/21–33
35 exp Diabetes Insipidus/
36 (diabet$ adj3 (insipidus not mellitus)).mp.
37 or/35–36
38 34 not 37
39 Self Help Groups/
40 Health Education/
41 Patient Education/
42 Patient Care/
43 Adolescent Psychology/
44 Child Psychology/
45 Behavior Therapy/
46 Cognitive Therapy/
47 Family Therapy/
48 Counseling/
49 exp patient care management/ and diabet$.mp.
50 exp Nutrition Therapy/
51 exp Home Care Services/
52 exp School Health Services/
53 (behav$ adj3 (therap$ or modif$)).mp.
54 (family adj3 therap$).mp.
55 ed.fs.
56 (video$ or gam$).mp.
57 (phone or telephon$).mp.
58 program$.mp.
59 interven$.mp.
60 inform$.mp.
61 educat$.mp.
62 teach$.mp.
63 train$.mp.
64 instruct$.mp.
65 ((diet or nutrition$) adj2 therap$).mp.
66 (diabet$ adj diet$).mp.
67 ((education$ or home) adj2 (meeting? or session? or strateg$ or workshop? or visit?)).mp.
68 ((psycho-$ or psycho$) and diabet$).mp.
69 or/39–68
70 Hemoglobin A, Glycosylated/
71 Blood Glucose/
72 Diabetic Ketoacidosis/
73 (ketoacido$ or keto-acido$).mp.
74 DKA.mp.
75 SMBG.mp.
76 (blood glucose or BG).mp.
77 ((metabolic or diabet$ or glyc?emic or glucose) adj control).mp.
78 ((glycosylated or glycated) adj3 (hemoglobin or haemoglobin)).mp.
79 (HbA1c or A1c or HbA1 or GHb or hemoglobin A1c or haemoglobin A1c).mp.
80 exp Self Care/
81 Self efficacy/
82 (self adj (care or regulat$ or monitor$ or manage$ or efficacy)).mp.
83 “Outcome Assessment (Health Care)”/
84 Program Evaluation/
85 Treatment Outcome/
86 exp Attitude to Health/
87 exp Health Behavior/
88 Problem Solving/
89 ((effect? or impact or evaluat$ or compar$) adj2 (treatment or care) adj program$).mp.
90 attitud$.mp.
91 behavio?r$.mp.
92 complian$.mp.
93 adheren$.mp.
94 improv$.mp.
95 chang$.mp.
96 (cope or coping).mp.
97 skill?.mp.
98 (knowledge or learn$ or cognition).mp.
99 Quality of Life/
100 “quality of life”.mp.
101 exp Hospitalization/
102 hospitali?ation?.mp.
103 admission?.mp.
104 service utilization.mp.
105 or/70–104
106 clinical trial.pt.
107 randomi?ed.ti,ab.
108 placebo.ti,ab.
109 dt.fs.
110 randomly.ti,ab.
111 trial.ti,ab.
112 groups.ti,ab.
113 or/106–112
114 animals/
115 humans/
116 114 not (114 and 115)
117 113 not 116
118 exp controlled clinical trials/
119 exp cohort studies/
120 Intervention Studies/
121 evaluation studies/ or program evaluation/
122 random allocation/
123 (pre test$ or pretest$ or (post test$ or posttest$)).mp.
124 (observation$ or prospectiv$ or cohort$ or control$ or volunteer$ or evaluat$ or compar$ or longitudinal or long term or long-term or longterm or case control$ or case-control$ or case referrent or case-referrent or time series or time-series or followup or follow up or follow-up or before-and-after or before-after).mp. and (study or studies or trial$).ti,ab,sh.
125 or/118–124
126 125 not 116
127 117 or 126
128 (letter$ or editorial$ or comment$ or lecture$).pt.
129 127 not 128
130 and/20,38,69,105,129
131 limit 130 to english language
132 limit 131 to yr=“1983-2007”

## Table B2. Ovid MEDLINE^®^ In-Process and Other Non-Indexed Citations—OVID Version: rel10.4.1

Years/issue searched: March 02, 2007

Search date: March 4, 2007

Results: study design 68; no study design 122

1 infan$.mp.
2 (baby or babies).mp.
3 child$.mp.
4 toddler$.mp.
5 adolescen$.mp.
6 (young adj3 (person? or people or adult?)).mp.
7 (teen$ or teen ager?).mp.
8 youth?.mp.
9 juvenil$.mp.
10 pube$.mp.
11 parent$.mp.
12 famil$.mp.
13 (caregiv$ or care giv$ or care-giv$ or caretak$ or care tak$ or care-tak$ or carer?).mp.
14 or/1–13
15 ((type 1 or type I) adj (diabetes mellitus or DM)).mp.
16 ((diabetes mellitus or DM) adj (type 1 or type I)).mp.
17 diabet$.mp.
18 IDDM.mp.
19 DM.mp.
20 ((insulin-dependent or insulindependent) adj3 (diabetes mellitus or DM)).mp.
21 ((earl$ or juvenil$ or child$ or labil$ or keto$) adj3 (diabetes mellitus or DM)).mp.
22 ((autoimmun$ or auto-immun$ or auto immun$ or sudden onset) adj3 (diabetes mellitus or DM)).mp.
23 (insulin defic$ adj3 absolut$).mp.
24 hypoglyc?emi$.mp.
25 or/15–24
26 (diabet$ adj3 (insipidus not mellitus)).mp.
27 25 not 26
28 (patient adj (care or management)).mp.
29 health services.mp.
30 ((child or adolescent) adj3 psychology).mp.
31 counsel?ing.mp.
32 ((behav$ or cognitiv$) adj3 (therap$ or modif$)).mp.
33 (family adj3 therap$).mp.
34 (video$ or gam$).mp.
35 (phone or telephon$).mp.
36 program$.mp.
37 interven$.mp.
38 inform$.mp.
39 educat$.mp.
40 teach$.mp.
41 train$.mp.
42 instruct$.mp.
43 ((diet or nutrition$) adj2 therap$).mp.
44 (diabet$ adj diet$).mp.
45 ((education$ or home) adj2 (meeting? or session? or strateg$ or workshop? or visit?)).mp.
46 ((psycho-$ or psycho$) and diabet$).mp.
47 or/28–46
48 (blood glucose or BG).mp.
49 (ketoacido$ or keto-acido$).mp.
50 DKA.mp.
51 SMBG.mp.
52 ((metabolic or diabet$ or glyc?emic or glucose) adj control).mp.
53 ((glycosylated or glycated) adj3 (hemoglobin or haemoglobin)).mp.
54 (HbA1c or A1c or HbA1 or GHb or hemoglobin A1c or haemoglobin A1c).mp.
55 (self adj (care or regulat$ or monitor$ or manage$ or efficacy)).mp.
56 “Outcome and Assessment (Health Care)”.mp.
57 treatment outcome$.mp.
58 problem solving.mp.
59 ((effect? or impact or evaluat$ or compar$) adj2 (treatment or care) adj program$).mp.
60 attitud$.mp.
61 behavio?r$.mp.
62 complian$.mp.
63 adheren$.mp.
64 improv$.mp.
65 chang$.mp.
66 (cope or coping).mp.
67 skill?.mp.
68 (knowledge or learn$ or cognition).mp.
69 “quality of life”.mp.
70 hospitali?ation?.mp.
71 admission?.mp.
72 service utilization.mp.
73 or/48–72
74 clinical trial.pt.
75 randomi?ed.ti,ab.
76 placebo.ti,ab.
77 randomly.ti,ab.
78 trial.ti,ab.
79 groups.ti,ab.
80 (pre test$ or pretest$ or (post test$ or posttest$)).mp.
81 (observation$ or prospectiv$ or cohort$ or control$ or volunteer$ or evaluat$ or compar$ or longitudinal or long term or long-term or longterm or case control$ or case-control$ or case referrent or case-referrent or time series or time-series or followup or follow up or follow-up or before-and-after or before-after).mp. and (study or studies or trial$).ti,ab,sh.
82 or/74–81
83 (letter$ or editorial$ or comment$ or lecture$).pt.
84 and/14,27,47,73,82
85 84 not 83
86 limit 85 to (english language and yr=“1983 - 2007”)

## Table B3. EMBASE—OVID Version: rel10.4.1

Years/issues searched: 1988 to 2007 Week 09

Search date: March 4, 2007

Results: study design 5,824; no study design 7,805

1 exp child/
2 exp childhood/
3 exp adolescent/
4 exp adolescence/
5 exp family/
6 caregiver/
7 infan$.mp.
8 (baby or babies).mp.
9 child$.mp.
10 toddler$.mp.
11 adolescen$.mp.
12 (young adj3 (person? or people or adult?)).mp.
13 (teen$ or teen ager?).mp.
14 youth?.mp.
15 juvenil$.mp.
16 pube$.mp.
17 parent$.mp.
18 famil$.mp.
19 (caregiv$ or care giv$ or care-giv$ or caretak$ or care tak$ or care-tak$ or carer?).mp.
20 or/1–19
21 diabetes mellitus/
22 exp hypoglycemia/
23 ((type 1 or I) adj (diabetes mellitus or DM)).mp.
24 ((diabetes mellitus or DM) adj (type 1 or type I)).mp.
25 diabet$.mp.
26 IDDM.mp.
27 DM.mp.
28 ((insulin-dependent or insulindependent) adj3 (diabetes mellitus or DM)).mp.
29 ((earl$ or juvenil$ or child$ or labil$ or keto$) adj3 (diabetes mellitus or DM)).mp.
30 (insulin defic$ adj3 absolut$).mp.
31 hypogly?emi$.mp.
32 ((autoimmun$ or auto-immun$ or auto immun$ or sudden onset) adj3 (diabetes mellitus or DM)).mp.
33 or/21–32
34 exp diabetes insipidus/
35 (diabet$ adj3 (insipidus not mellitus)).mp.
36 or/34–35
37 33 not 36
38 exp health service/
39 health education/
40 diabetes education/
41 nutrition education/
42 patient education/
43 child psychology/
44 behavior therapy/
45 cognitive therapy/
46 family therapy/
47 exp counseling/
48 exp diet therapy/
49 (behav$ adj3 (therap$ or modif$)).mp.
50 (family adj3 therap$).mp.
51 (video$ or gam$).mp.
52 (phone or telephon$).mp.
53 program$.mp.
54 interven$.mp.
55 inform$.mp.
56 educat$.mp.
57 teach$.mp.
58 train$.mp.
59 instruct$.mp.
60 ((diet or nutrition$) adj2 therap$).mp.
61 (diabet$ adj diet$).mp.
62 ((education$ or home) adj2 (meeting? or session? or strateg$ or workshop? or visit?)).mp.
63 ((psycho-$ or psycho$) and diabet$).mp.
64 or/38–63
65 exp Hemoglobin/
66 glucose blood level/
67 (ketoacido$ or keto-acido$).mp.
68 DKA.mp.
69 SMBG.mp.
70 (blood glucose or BG).mp.
71 ((metabolic or diabet$ or glyc?emic or glucose) adj control).mp.
72 (self adj (care or regulat$ or monitor$ or manage$ or efficacy)).mp.
73 ((glycosylated or glycated) adj3 (hemoglobin or haemoglobin)).mp.
74 (HbA1c or A1c or HbA1 or GHb or hemoglobin A1c or haemoglobin A1c).mp.
75 exp Self Care/
76 exp self concept/
77 exp treatment outcome/
78 attitude to health/
79 exp Health Behavior/
80 Problem Solving/
81 decision making/
82 ((effect? or impact or evaluat$ or compar$) adj2 (treatment or care) adj program$).mp.
83 attitud$.mp.
84 behavio?r$.mp.
85 complian$.mp.
86 adheren$.mp.
87 improv$.mp.
88 chang$.mp.
89 (cope or coping).mp.
90 skill?.mp.
91 (knowledge or learn$ or cognition).mp.
92 Quality of Life/
93 “quality of life”.mp.
94 hospitalization/
95 hospitali?ation?.mp.
96 admission?.mp.
97 service utilization.mp.
98 or/65–97
99 exp clinical trial/
100 randomi?ed.ti,ab.
101 placebo.ti,ab.
102 (ae or dt or to).fs.
103 randomly.ti,ab.
104 trial.ti,ab.
105 groups.ti,ab.
106 cohort analysis/
107 time Series Analysis/
108 (pre test$ or pretest$ or (post test$ or posttest$)).mp.
109 (observation$ or prospectiv$ or cohort$ or control$ or volunteer$ or evaluat$ or compar$ or longitudinal or long term or long-term or longterm or case control$ or case-control$ or case referrent or case-referrent or time series or time-series or followup or follow up or follow-up or before-and-after or before-after).mp. and (study or studies or trial$).ti,ab,sh.
110 or/99–109
111 ANIMAL/
112 Human/
113 111 not (111 and 112)
114 110 not 113
115 and/20,37,64,98,114
116 (letter$ or editorial$ or note$).pt.
117 115 not 116
118 limit 117 to (english language and yr=“1983 - 2007”)

## Table B4. EBM Reviews—Cochrane Central Register of Controlled Trials

Years/issue searched: 1^st^ Quarter 2007

Search date: March 4, 2007

Results: 741

1 exp Infant/
2 exp Family/
3 exp Caregiver/
4 infan$.mp.
5 (baby or babies).mp.
6 child$.mp.
7 toddler$.mp.
8 adolescen$.mp.
9 (young adj3 (person? or people or adult?)).mp.
10 (teen$ or teen ager?).mp.
11 youth?.mp.
12 juvenil$.mp.
13 pube$.mp.
14 parent$.mp.
15 famil$.mp.
16 (caregiv$ or care giv$ or care-giv$ or caretak$ or care tak$ or care-tak$ or carer?).mp.
17 or/1–16
18 exp Diabetes Mellitus/
19 exp Hypoglycemia/
20 diabetes mellitus type 1.sh.
21 ((type 1 or type I) adj (diabetes mellitus or DM)).mp.
22 ((diabetes mellitus or DM) adj (type 1 or type I)).mp.
23 diabet$.mp.
24 IDDM.mp.
25 DM.mp.
26 ((insulin-dependent or insulindependent) adj3 (diabetes mellitus or DM)).mp.
27 ((earl$ or juvenil$ or child$ or labil$ or keto$) adj3 (diabetes mellitus or DM)).mp.
28 ((autoimmun$ or auto-immun$ or auto immun$ or sudden onset) adj3 (diabetes mellitus or DM)).mp.
29 (insulin defic$ adj3 absolut$).mp.
30 hypoglyc?emi$.mp.
31 or/18–30
32 exp Diabetes Insipidus/
33 (diabet$ adj3 (insipidus not mellitus)).mp.
34 or/32–33
35 31 not 34
36 Self Help Groups/
37 health education/
38 patient education/
39 exp patient care/
40 exp health services/
41 Adolescent Psychology/
42 Child Psychology/
43 Behavior Therapy/
44 Family Therapy/
45 Counseling/
46 exp patient care management/ and diabet$.mp.
47 (behav$ adj3 (therap$ or modif$)).mp.
48 (family adj3 therap$).mp.
49 ed.fs.
50 (video$ or gam$).mp.
51 (phone or telephon$).mp.
52 program$.mp.
53 interven$.mp.
54 inform$.mp.
55 educat$.mp.
56 teach$.mp.
57 train$.mp.
58 instruct$.mp.
59 ((diet or nutrition$) adj2 therap$).mp.
60 (diabet$ adj diet$).mp.
61 ((education$ or home) adj2 (meeting? or session? or strateg$ or workshop? or visit?)).mp.
62 ((psycho-$ or psycho$) and diabet$).mp.
63 or/36–62
64 Hemoglobin A, Glycosylated/
65 Blood Glucose/
66 diabetic ketoacidosis/
67 DKA.mp.
68 SMBG.mp.
69 ((metabolic or diabet$ or glyc?emic or glucose) adj control).mp.
70 ((glycosylated or glycated) adj3 (hemoglobin or haemoglobin)).mp.
71 (HbA1c or A1c or HbA1 or GHb or hemoglobin A1c or haemoglobin A1c).mp.
72 exp Self Care/
73 Self efficacy/
74 (self adj (care or regulat$ or monitor$ or manage$ or efficacy)).mp.
75 exp “Outcome and Process Assessment (Health Care)”/
76 exp Attitude to Health/
77 exp Health Behavior/
78 Problem Solving/
79 ((effect? or impact or evaluat$ or compar$) adj2 (treatment or care) adj program$).mp.
80 attitud$.mp.
81 behavio?r$.mp.
82 complian$.mp.
83 adheren$.mp.
84 improv$.mp.
85 chang$.mp.
86 (cope or coping).mp.
87 skill?.mp.
88 (knowledge or learn$ or cognition).mp.
89 “quality of life”.mp.
90 exp hospitalization/
91 hospitali?ation?.mp.
92 admission?.mp.
93 service utilization.mp.
94 or/64–93
95 Intervention Studies/
96 evaluation studies/ or program evaluation/
97 (pre test$ or pretest$ or (post test$ or posttest$)).mp.
98 (observation$ or prospectiv$ or cohort$ or control$ or volunteer$ or evaluat$ or compar$ or longitudinal or long term or long-term or longterm or case control$ or case-control$ or case referrent or case-referrent or time series or time-series or followup or follow up or follow-up or before-and-after or before-after).mp. and (study or studies or trial$).ti,ab,sh.
99 or/95–98
100 animals/
101 99 not 100
102 and/17,35,63,94,101
103 (letter$ or editorial$ or comment$ or lecture$ or note$).pt.
104 102 not 103
105 limit 104 to yr=“1983 - 2006”

## Table B5. EBM Cochrane Database of Systematic Reviews (CDSR) and EBM Database of Reviews and Abstracts (DARE)—OVID Version: rel10.4.1

Years/issue searched: 1^st^ Quarter 2007

Search date: March 4, 2007

Results: CDSR 490; DARE 106

1 infan$.mp.
2 (baby or babies).mp.
3 child$.mp.
4 toddler$.mp.
5 adolescen$.mp.
6 (young adj3 (person? or people or adult?)).mp.
7 (teen$ or teen ager?).mp.
8 youth?.mp.
9 juvenil$.mp.
10 pube$.mp.
11 parent$.mp.
12 famil$.mp.
13 (caregiv$ or care giv$ or care-giv$ or caretak$ or care tak$ or care-tak$ or carer?).mp.
14 or/1–13
15 ((type 1 or type I) adj (diabetes mellitus or DM)).mp.
16 ((diabetes mellitus or DM) adj (type 1 or type I)).mp.
17 diabet$.mp.
18 IDDM.mp.
19 DM.mp.
20 ((insulin-dependent or insulindependent) adj3 (diabetes mellitus or DM)).mp.
21 ((earl$ or juvenil$ or child$ or labil$ or keto$) adj3 (diabetes mellitus or DM)).mp.
22 ((autoimmun$ or auto-immun$ or auto immun$ or sudden onset) adj3 (diabetes mellitus or DM)).mp.
23 (insulin defic$ adj3 absolut$).mp.
24 hypoglyc?emi$.mp.
25 or/15–24
26 (diabet$ adj3 (insipidus not mellitus)).mp.
27 25 not 26
28 (patient adj (care or management)).mp.
29 health services.mp.
30 ((child or adolescent) adj3 psychology).mp.
31 counsel?ing.mp.
32 ((behav$ or cognitiv$) adj3 (therap$ or modif$)).mp.
33 (family adj3 therap$).mp.
34 (video$ or gam$).mp.
35 (phone or telephon$).mp.
36 program$.mp.
37 interven$.mp.
38 inform$.mp.
39 educat$.mp.
40 teach$.mp.
41 train$.mp.
42 instruct$.mp.
43 ((diet or nutrition$) adj2 therap$).mp.
44 (diabet$ adj diet$).mp.
45 ((education$ or home) adj2 (meeting? or session? or strateg$ or workshop? or visit?)).mp.
46 ((psycho-$ or psycho$) and diabet$).mp.
47 or/28–46
48 (blood glucose or BG).mp.
49 (ketoacido$ or keto-acido$).mp.
50 DKA.mp.
51 SMBG.mp.
52 ((metabolic or diabet$ or glyc?emic or glucose) adj control).mp.
53 ((glycosylated or glycated) adj3 (hemoglobin or haemoglobin)).mp.
54 (HbA1c or A1c or HbA1 or GHb or hemoglobin A1c or haemoglobin A1c).mp.
55 (self adj (care or regulat$ or monitor$ or manage$ or efficacy)).mp.
56 “Outcome and Assessment (Health Care)”.mp.
57 treatment outcome$.mp.
58 problem solving.mp.
59 ((effect? or impact or evaluat$ or compar$) adj2 (treatment or care) adj program$).mp.
60 attitud$.mp.
61 behavio?r$.mp.
62 complian$.mp.
63 adheren$.mp.
64 improv$.mp.
65 chang$.mp.
66 (cope or coping).mp.
67 skill?.mp.
68 (knowledge or learn$ or cognition).mp.
69 “quality of life”.mp.
70 hospitali?ation?.mp.
71 admission?.mp.
72 service utilization.mp.
73 or/48–72
74 and/14,27,47

## Table B6. OVID Healthstar—OVID Version: rel10.4.1

Years/issues searched: 1966 to January 2007

Search date: March 4, 2007

Results: study design 3,631; no study design 5,591

1 exp Infant/
2 exp Child/
3 exp Adolescent/
4 exp Parents/
5 exp Family/
6 exp Caregivers/
7 infan$.mp.
8 (baby or babies).mp.
9 child$.mp.
10 toddler$.mp.
11 adolescen$.mp.
12 (young adj3 (person? or people or adult?)).mp.
13 (teen$ or teen ager?).mp.
14 youth?.mp.
15 juvenil$.mp.
16 pube$.mp.
17 parent$.mp.
18 famil$.mp.
19 (caregiv$ or care giv$ or care-giv$ or caretak$ or care tak$ or care-tak$ or carer?).mp.
20 or/1–19
21 Diabetes Mellitus/
22 Diabetes Mellitus, Type 1/
23 exp hypoglycemia/
24 ((type 1 or type I) adj (diabetes mellitus or DM)).mp.
25 ((diabetes mellitus or DM) adj (type 1 or type I)).mp.
26 diabet$.mp.
27 IDDM.mp.
28 DM.mp.
29 ((insulin-dependent or insulindependent) adj3 (diabetes mellitus or DM)).mp.
30 ((earl$ or juvenil$ or child$ or labil$ or keto$) adj3 (diabetes mellitus or DM)).mp.
31 ((autoimmun$ or auto-immun$ or auto immun$ or sudden onset) adj3 (diabetes mellitus or DM)).mp.
32 (insulin defic$ adj3 absolut$).mp.
33 hypoglyc?emi$.mp.
34 or/21–33
35 exp Diabetes Insipidus/
36 (diabet$ adj3 (insipidus not mellitus)).mp.
37 or/35–36
38 34 not 37
39 Self Help Groups/
40 Health Education/
41 Patient Education/
42 Patient Care/
43 Adolescent Psychology/
44 Child Psychology/
45 Behavior Therapy/
46 Cognitive Therapy/
47 Family Therapy/
48 Counseling/
49 exp patient care management/ and diabet$.mp.
50 exp Nutrition Therapy/
51 exp Home Care Services/
52 exp School Health Services/
53 (behav$ adj3 (therap$ or modif$)).mp.
54 (family adj3 therap$).mp.
55 ed.fs.
56 (video$ or gam$).mp.
57 (phone or telephon$).mp.
58 program$.mp.
59 interven$.mp.
60 inform$.mp.
61 educat$.mp.
62 teach$.mp.
63 train$.mp.
64 instruct$.mp.
65 ((diet or nutrition$) adj2 therap$).mp.
66 (diabet$ adj diet$).mp.
67 ((education$ or home) adj2 (meeting? or session? or strateg$ or workshop? or visit?)).mp.
68 ((psycho-$ or psycho$) and diabet$).mp.
69 or/39–68
70 Hemoglobin A, Glycosylated/
71 Blood Glucose/
72 Diabetic Ketoacidosis/
73 (ketoacido$ or keto-acido$).mp.
74 DKA.mp.
75 SMBG.mp.
76 (blood glucose or BG).mp.
77 ((metabolic or diabet$ or glyc?emic or glucose) adj control).mp.
78 ((glycosylated or glycated) adj3 (hemoglobin or haemoglobin)).mp.
79 (HbA1c or A1c or HbA1 or GHb or hemoglobin A1c or haemoglobin A1c).mp.
80 exp Self Care/
81 Self efficacy/
82 (self adj (care or regulat$ or monitor$ or manage$ or efficacy)).mp.
83 “Outcome Assessment (Health Care)”/
84 Program Evaluation/
85 Treatment Outcome/
86 exp Attitude to Health/
87 exp Health Behavior/
88 Problem Solving/
89 ((effect? or impact or evaluat$ or compar$) adj2 (treatment or care) adj program$).mp.
90 attitud$.mp.
91 behavio?r$.mp.
92 complian$.mp.
93 adheren$.mp.
94 improv$.mp.
95 chang$.mp.
96 (cope or coping).mp.
97 skill?.mp.
98 (knowledge or learn$ or cognition).mp.
99 Quality of Life/
100 “quality of life”.mp.
101 exp Hospitalization/
102 hospitali?ation?.mp.
103 admission?.mp.
104 service utilization.mp.
105 or/70–104
106 clinical trial.pt.
107 randomi?ed.ti,ab.
108 placebo.ti,ab.
109 dt.fs.
110 randomly.ti,ab.
111 trial.ti,ab.
112 groups.ti,ab.
113 exp controlled clinical trials/
114 exp cohort studies/
115 Intervention Studies/
116 evaluation studies/ or program evaluation/
117 random allocation/
118 (pre test$ or pretest$ or (post test$ or posttest$)).mp.
119 (observation$ or prospectiv$ or cohort$ or control$ or volunteer$ or evaluat$ or compar$ or longitudinal or long term or long-term or longterm or case control$ or case-control$ or case referrent or case-referrent or time series or time-series or followup or follow up or follow-up or before-and-after or before-after).mp. and (study or studies or trial$).ti,ab,sh.
120 or/106–119
121 animals/ not human/
122 120 not 121
123 and/20,38,69,105,122
124 (letter$ or editorial$ or comment$ or lecture$).pt.
125 123 not 124
126 limit 125 to english language
127 limit 126 to yr=“1983-2007”

## Table B7. ERIC (Educational Resources Information Center)—OVID Version: rel10.4.1

Years/issue searched: 1966 to January 2007

Search date: March 4, 2007

Results: study design 220; no study design 222

1 infants/
2 Toddlers/
3 exp children/
4 early adolescents/
5 adolescents/
6 late adolescents/
7 preadolescents/
8 exp youth/
9 exp “family (sociological unit)”/
10 exp parents/
11 exp caregivers/
12 infan$.mp.
13 (baby or babies).mp.
14 toddler$.mp.
15 child$.mp.
16 adolescen$.mp.
17 (young adj3 (person? or people or adult?)).mp.
18 (teen$ or teen ager?).mp.
19 youth?.mp.
20 juvenil$.mp.
21 pube$.mp.
22 parent$.mp.
23 famil$.mp.
24 (caregiv$ or care giv$ or care-giv$ or caretak$ or care tak$ or care-tak$ or carer?).mp.
25 or/1–24
26 diabetes/
27 ((type 1 or type I) adj (diabetes mellitus or DM)).mp.
28 ((diabetes mellitus or DM) adj (type 1 or type I)).mp.
29 diabet$.mp.
30 IDDM.mp.
31 DM.mp.
32 ((insulin-dependent or insulindependent) adj3 (diabetes mellitus or DM)).mp.
33 ((earl$ or juvenil$ or child$ or labil$ or keto$) adj3 (diabetes mellitus or DM)).mp.
34 hypoglyc?emi$.mp.
35 or/26–34
36 (diabet$ adj3 (insipidus not mellitus)).mp.
37 35 not 36
38 exp health education/
39 Health Behavior/
40 health programs/
41 health promotion/
42 patient education/
43 Nutrition Instruction/
44 exp behavior modification/
45 exp counseling/
46 exp intervention/
47 self help programs/
48 social support groups/
49 cognitive restructuring/
50 exp health services/
51 school health services/
52 exp therapy/ and diabet$.mp.
53 child psychology/
54 exp educational methods/
55 exp instructional methods/
56 (behav$ adj3 (therap$ or modif$)).mp.
57 (family adj3 therap$).mp.
58 (video$ or gam$).mp.
59 (phone or telephon$).mp.
60 program$.mp.
61 interven$.mp.
62 inform$.mp.
63 educat$.mp.
64 teach$.mp.
65 train$.mp.
66 instruct$.mp.
67 ((diet or nutrition$) adj2 therap$).mp.
68 (diabet$ adj diet$).mp.
69 ((education$ or home) adj2 (meeting? or session? or strateg$ or workshop? or visit?)).mp.
70 ((psycho-$ or psycho$) and diabet$).mp.
71 or/38–70
72 (hemoglobin or haemoglobin).mp.
73 (HbA1c or A1c or HbA1 or GHb).mp.
74 (blood glucose or BG).mp.
75 (ketoacido$ or keto-acido$).mp.
76 ((metabolic or diabet$ or glyc?emic or glucose) adj control).mp.
77 self management/
78 self efficacy/
79 (self adj (care or regulat$ or monitor$ or manage$ or efficacy)).mp.
80 medical care evaluation/
81 program evaluation/
82 “outcomes of treatment”/
83 Behavior Change/
84 problem solving/
85 ((effect? or impact or evaluat$ or compar$) adj2 (treatment or care) adj program$).mp.
86 attitud$.mp.
87 behavio?r$.mp.
88 complian$.mp.
89 adheren$.mp.
90 improv$.mp.
91 chang$.mp.
92 (cope or coping).mp.
93 skill?.mp.
94 (knowledge or learn$ or cognition).mp.
95 exp “quality of life”/
96 “quality of life”.mp.
97 hospitali?ation?.mp.
98 admission?.mp.
99 service utilization.mp.
100 motivation/
101 or/72–100
102 control?ed clinical trial?.mp.
103 randomi?ed.ti,ab.
104 placebo.ti,ab.
105 randomly.ti,ab.
106 trial.ti,ab.
107 groups.ti,ab.
108 Evaluation Methods/ or Program Evaluation/
109 (pre test$ or pretest$ or (post test$ or posttest$)).mp.
110 (observation$ or prospectiv$ or cohort$ or control$ or volunteer$ or evaluat$ or compar$ or longitudinal or long term or long-term or longterm or case control$ or case-control$ or case referrent or case-referrent or time series or time-series or followup or follow up or follow-up or before-and-after or before-after).mp. and (study or studies or trial$).ti,ab,sh.
111 Cohort Analysis/
112 exp longitudinal studies/
113 or/101–112
114 exp animals/
115 113 not 114
116 and/25,37,71,101,115
117 (letter$ or editorial$ or commentary or lecture$).ti,ab.
118 116 not 117
119 limit 118 to (english language and yr=“1983 - 2007”)

## Table B8. PsycINFO^®^—OVID Version: rel10.4.1

Years/issue searched: 1985 to February Week 4 2007

Search date: March 4, 2007

Results: study design 468; no study design 1,141

1 infan$.mp.
2 (baby or babies).mp.
3 toddler$.mp.
4 child$.mp.
5 adolescen$.mp.
6 (young adj3 (person? or people or adult?)).mp.
7 (teen$ or teen ager?).mp.
8 youth?.mp.
9 juvenil$.mp.
10 pube$.mp.
11 parent$.mp.
12 famil$.mp.
13 (caregiver? or care-taker or care giver$? or caretaker? or care-taker? or care caker? or carer?).mp.
14 infancy 2 23 mo.ag.
15 childhood birth 12 yrs.ag.
16 preschool age 2 5 yrs.ag.
17 school age 6 12 yrs.ag.
18 adolescence 13 17 yrs.ag.
19 exp parents/
20 exp Family/
21 exp Caregivers/
22 or/1–21
23 diabetes/
24 diabetes mellitus/
25 hypoglycemia/
26 ((type 1 or I) adj (diabetes mellitus or DM)).mp.
27 ((diabetes mellitus or DM) adj (type 1 or I)).mp.
28 diabet$.mp.
29 IDDM.mp.
30 DM.mp.
31 ((insulin-dependent or insulindependent) adj3 (diabetes mellitus or DM)).mp.
32 ((earl$ or juvenil$ or child$ or labil$ or keto$) adj3 (diabetes mellitus or DM)).mp.
33 ((autoimmun$ or auto-immun$ or auto immun$ or sudden onset) adj3 (diabetes mellitus or DM)).mp.
34 (insulin defic$ adj3 absolut$).mp.
35 hypoglyc?emi$.mp.
36 or/23–35
37 exp Diabetes Insipidus/
38 (diabet$ adj (insipidus not mellitus)).mp.
39 36 not 38
40 health education/
41 health promotion/
42 client education/
43 behavior modification/
44 behavior therapy/
45 cognitive therapy/
46 cognitive behavior therapy/
47 exp counseling/
48 interdisciplinary treatment approach/
49 Multimodal Treatment Approach/
50 exp health care delivery/
51 exp Health Care Services/
52 exp case management/
53 support groups/
54 exp intervention/
55 health behavior/
56 exp psychotherapy/ and diabet$.mp.
57 (behav$ adj3 (therap$ or modif$)).mp.
58 (family adj3 therap$).mp.
59 (video$ or gam$).mp.
60 (phone or telephon$).mp.
61 program$.mp.
62 interven$.mp.
63 inform$.mp.
64 educat$.mp.
65 teach$.mp.
66 train$.mp.
67 instruct$.mp.
68 ((diet or nutrition$) adj2 therap$).mp.
69 (diabet$ adj diet$).mp.
70 ((education$ or home) adj2 (meeting? or sesion? or strateg$ or workshop? or visit?)).mp.
71 child psychology/ and diabet$.mp.
72 adolescent psychology/ and diabet$.mp.
73 ((psycho-$ or psycho$) and diabet$).mp.
74 “Psychoanalytic Therapy”.cc.
75 “Behavioral & Psychological Treatment of Physical Illness”.cc.
76 or/40–75
77 blood sugar/
78 hemoglobin/
79 self monitoring/
80 DKA.mp.
81 (ketoacido$ or keto-acido$).mp.
82 SMBG.mp.
83 (self adj (care or regulat$ or monitor$ or manage$ or efficacy)).mp.
84 (blood glucose or BG).mp.
85 ((metabolic or diabet$ or glyc?emic or glucose) adj control).mp.
86 ((glycosylated or glycated) adj3 (hemoglobin or haemoglobin)).mp.
87 (HbA1c or A1c or HbA1 or GHb or hemoglobin A1c or haemoglobin A1c).mp.
88 self efficacy/
89 exp self management/
90 exp treatment outcomes/
91 Treatment Effectiveness Evaluation/
92 exp program evaluation/
93 health attitudes/
94 “physical illness (attitudes toward)”/
95 problem solving/
96 treatment compliance/
97 ((effect? or impact? or evaluat$ or compar$) adj2 (treatment or care) adj program$).mp.
98 attitud$.mp.
99 behavio?r.mp.
100 complian$.mp.
101 adheren$.mp.
102 improv$.mp.
103 chang$.mp.
104 (cope or coping).mp.
105 skill?.mp.
106 (knowledge or learn$ or cognition).mp.
107 “quality of life”/
108 “quality of life”.mp.
109 exp hospitalization/
110 hospitali?ation?.mp.
111 admission?.mp.
112 health care utilization/
113 service utilization.mp.
114 or/77–113
115 clinical trials/
116 randomi?ed.ti,ab.
117 placebo.ti,ab.
118 randomly.ti,ab.
119 trial.ti,ab.
120 groups.ti,ab.
121 “research design$”.mp.
122 cohort analysis/
123 Followup Studies/
124 exp Longitudinal Studies/
125 exp program evaluation/
126 random sampling/
127 (pre test$ or pretest$ or (post test$ or posttest$)).mp.
128 (observation$ or prospectiv$ or cohort$ or control$ or volunteer$ or evaluat$ or compar$ or longitudinal or long term or long-term or longterm or case control$ or case-control$ or case referrent or case-referrent or time series or time-series or followup or follow up or follow-up or before-and-after or before-after).mp. and (study or studies or trial$).ti,ab,sh.
129 or/115–128
130 exp Animals/
131 129 not 130
132 and/22,39,76,114,131
133 (letter$ or editorial$ or lecture$ or commentary).ti,ab.
134 132 not 133
135 limit 134 to (english language and yr=“1983 - 2007”)

## Table B9. CINAHL Plus with Full Text—EBSCOhost

Years/issue searched: 1937 to present

Search date: March 5, 2007

Limits: not applied (not working day searches were run)

Results: study design 646; no study design 2,383

1 ( MH “Child+” or MH “Adolescence+” or MH “Family+” or MH “Caregivers” or infan* or baby or babies or child* or toddler* or adolescent* or young w3 person? or young w3 adult? or young w3 people or teen* or teen ager? or teen-ager? or youth? or juvenil* or pube* or parent* or family or families or caregiv* or care giv* or care-giv* or caretak* or care tak* or care-tak* or carer? ) and ( MH “Diabetes Mellitus” or MH “Diabetes Mellitus, Insulin-Dependent” or MH “Hypoglycemia+” or type 1 diabetes or type I diabetes or diabet* or iddm or dm or earl* w3 diabetes or juvenil* w3 diabetes or child* w3 diabetes or labil* w3 diabetes or keto* w3 diabetes or auto immun* w3 diabetes or auto-immun* w3 diabetes or autoimmun* w3 diabetes or sudden onset w3 diabetes or insulin defic* n3 absolut* or hypoglyc?emi* ) and ( MH “Support Groups” or MH “Health Education+” or MH “Patient Care+” or MH “Child Psychology” or MH “Adolescent Psychology” or MH “Behavior Therapy” or MH “Cognitive Therapy” or MH “Family Therapy” or MH “Counseling” or behav* n3 therap* or behave* n3 modif* or family n3 therap* or family n3 modif* or MW “Education” or video* or game? or gaming or phone or telephon* or program* or interven* or inform* or educat* or teach* or train* or instruct* or psycho* or diet w2 therap* or nutrition w2 therap* or diabet* diet* ) and ( HbA1c or A1c or HbA1 or GHb or hemoglobin A1c or haemoglobin A1c or MH “Self Care+” or MH “Self-Efficacy” or MH “Outcomes (Health Care)+” or MH “Program Evaluation” or MH “Attitude to Health+” or MH “Health Behavior+” or MH “Problem Solving” or MH “Quality of Life” or MH “Institutionalization+” or self w2 care or self w2 regulat* or self w2 monitor* or self w2 manage* or self w2 efficacy or effect? or impact or evaluat* or compar* n2 treatment or care w1 program* or attitud* or behavio?r* or complian* or adheren* or improv* or cope or coping or skill? or knowledge or learn* or cognition or “quality of life” or hospitali?ation? or admission? or service utilization or MH “Coping+” or MH “Adaptation, Psychological” or MH “Health Resource Utilization” or MH “Health Services+/UT” )
2 ( MH “Clinical Trials+” or MH “Case Control Studies” or MH “Multiple Time Series” or MH “Time series” or MH “Concurrent Prospective Studies” or MH “Prospective Studies” or MH “Research Methodology” or MH “Pretest-Posttest Design+” or MH “Experimental studies” or MH “Comparative Studies” or MH “Evaluation Research+” or MH “Program Evaluation” or MH “Evaluation” or MH “Random Assignment” )
3 #1 and #2

## Table B10. LILACS (Latin American and Caribbean Health Science Literature) (via OCLC WorldCat)

Search date: February 28, 2007

Limits: 1983-2007; English

Results: 800

1 (kw: diabetes w mellitus OR kw: Diabetes w Mellitus, w Type w 1 OR kw: Diabetic w Ketoacidosis OR kw: DM OR kw: IDDM OR ((kw: diabetes w mellitus OR kw: DM) AND (kw: type and kw: 1) OR (kw: type and kw: I))) OR ((kw: insulin-depend* OR kw: insulindepend* OR kw: keto* OR kw: earl* OR kw: juvenil* OR kw: child* OR kw: labil* OR kw: autoimmun* OR kw: auto-immun* OR (kw: sudden and kw: onset)) AND (kw: diabet* OR kw: DM)) OR (((kw: insulin and kw: def*) AND kw: absolut*) OR kw: hypoglycemi*) and yr: 1983-2007 and la= “eng” and li: lilac

## Table B11. OCLC ProceedingsFirst—OCLC First Search

Limits: 1983-2007; English

Search date: February 28, 2007

Results: 14

1 kw: infant+ OR kw: baby OR kw: babies OR kw: toddler+ OR kw: child* OR kw: adolescent+ OR kw: teen* OR kw: teenager+ OR kw: youth+ OR kw: juvenile+ OR kw: parent+ OR kw: family OR kw: families OR kw: caregiver+ OR kw: caretaker+ OR kw: carer+ and yr: 1983-2007 and ln=“english”) and ((kw: diabetes w mellitus OR kw: Diabetes w Mellitus, w Type w 1 OR kw: Diabetic w Ketoacidosis OR kw: DM OR kw: IDDM OR ((kw: diabetes w mellitus OR kw: DM) AND (kw: type and kw: 1) OR (kw: type and kw: I))) OR ((kw: insulin-depend* OR kw: insulindepend* OR kw: keto* OR kw: earl* OR kw: juvenil* OR kw: child* OR kw: labil* OR kw: autoimmun* OR kw: auto-immun* OR (kw: sudden and kw: onset)) AND (kw: diabet* OR kw: DM)) OR (((kw: insulin and kw: def*) AND kw: absolut*) OR kw: hypoglycemi*) and yr: 1983-2007 and ln=“english”)

## Table B12. OCLC PapersFirst—OCLC First Search

Limits: 1983-2007

Search date: February 28, 2007

Results: 10

1 kw: infant+ OR kw: baby OR kw: babies OR kw: toddler+ OR kw: child* OR kw: adolescent+ OR kw: teen* OR kw: teenager+ OR kw: youth+ OR kw: juvenile+ OR kw: parent+ OR kw: family OR kw: families OR kw: caregiver+ OR kw: caretaker+ OR kw: carer+ and yr: 1983-2007 and ln=“english”) and ((kw: diabetes w mellitus OR kw: Diabetes w Mellitus, w Type w 1 OR kw: Diabetic w Ketoacidosis OR kw: DM OR kw: IDDM OR ((kw: diabetes w mellitus OR kw: DM) AND (kw: type and kw: 1) OR (kw: type and kw: I))) OR ((kw: insulin-depend* OR kw: insulindepend* OR kw: keto* OR kw: earl* OR kw: juvenil* OR kw: child* OR kw: labil* OR kw: autoimmun* OR kw: auto-immun* OR (kw: sudden and kw: onset)) AND (kw: diabet* OR kw: DM)) OR (((kw: insulin and kw: def*) AND kw: absolut*) OR kw: hypoglycemi*) and yr: 1983-2007

## Table B13. PubMed^®^—U.S. National Library of Medicine

Search date: March 6, 2007

Limits: articles published and/or entered within last 180 days

Results: 218

1 Search infant[MeSH] OR child[MeSH] OR adolescent[MeSH] OR parents[MeSH] OR family[MeSH] OR caregivers[MeSH]) OR (infan* OR baby OR babies OR toddler* OR child* OR adolescen* OR “young person*” OR “young people” OR “young adult*” OR teen* OR “teen-ager*” OR youth* OR juvenil* OR pube* OR parent* OR famil* OR caregiv* OR care-giv* OR caretak* OR “care-t*” OR carer*)
2 Search (“diabetes mellitus”[MeSH] OR “Diabetes Mellitus, Type 1”[MeSH] OR “Diabetic Ketoacidosis”[MeSH] OR DM OR IDDM OR ((“diabetes mellitus” OR DM) AND type 1 OR type I)) OR ((insulin-depend* OR insulindepend* OR keto* OR earl* OR juvenil* OR child* OR labil* OR autoimmun* OR auto-immun* OR sudden onset) AND (diabet* OR DM)) OR ((insulin def* AND absolut*) OR hypoglycemi*)
3 Search diabetes insipidus[MeSH]
4 Search ((#2)) NOT (#3)
5 Search self help groups[MeSH] OR health education[MeSH] OR patient education[MeSH] OR patient care[MeSH] OR adolescent psychology[MeSH] OR child psychology[MeSH] OR behavior therapy[MeSH] OR cognitive therapy[MeSH] OR family therapy[MeSH] OR counseling[MeSH] OR (exp patient care management[MeSH] AND diabet*) OR exp nutrition therapy[MeSH] OR exp home care services[MeSH] OR (behav* AND (therap* OR modif*)) OR (family AND therap*) OR video OR videos OR game OR games OR phone OR telphon* OR program* OR interven* OR inform* OR educat* OR teach* OR train* OR instruct*
6 Search ((Patient AND (Care OR management)) OR “Self-help group*” OR ((Health OR patient) AND education) OR Counsel* OR ((adolescent OR child) AND psychology) OR (behavio* OR cognit* OR psychotherap* OR family OR nutrition* OR diet*) AND (therap* OR (modif*)) OR "Home care service* OR school health service* OR diabet* diet*)
7 Search ((#5)) OR (#6)
8 Search Hemoglobin A, glycosylated[MeSH] OR blood glucose[MeSH] OR diabetic ketoacidosis[MeSH] OR ketoacido* OR keto-acido* OR DKA OR SMBG OR “blood glucose” OR BG OR ((metabolic OR diabet* OR glycemic OR glycaemic OR glucose) AND control) OR (HbA1c OR A1c OR HbA1 OR GHb OR hemoglobin OR haemoglobin)
9 Search Self care[MeSH] OR self efficacy[MeSH] OR (self AND (care OR regulat* OR monitor* OR manage* OR efficacy)) OR (attitud* OR behavior* OR complian* OR adheren* OR improv* OR chang* OR cope OR coping OR skill* OR knowledge OR learn* OR cognition))
10 Search Program evaluation[MeSH] OR treatment outcome[MeSH] OR attitude to health[MeSH] OR health behavior[MeSH] OR problem solving[MeSH] OR ((effect* OR impact OR evaluat* OR compar*) AND (treatment OR care) AND program*) OR “outcome assessment (health care)”[MeSH] OR quality of life[MeSH] OR hospitalization[MeSH] OR admission* OR “service utilization”
11 Search (((#8)) OR (#9)) OR (#10)
12 Search clinical trial[PT] OR randomized[TIAB] OR placebo[TIAB] OR randomly[TIAB] OR trial[TIAB] OR groups[TIAB] OR controlled clinical trials[MeSH] OR cohort studies[MeSH] OR intervention studies[MeSH] OR evaluation studies[MeSH] OR program evaluation[MeSH] OR random allocation[MeSH]
13 Search pre-test* OR pretest* OR post-test* OR posttest*
14 Search (observation*[TIAB] OR prospectiv*[TIAB] OR cohort*[TIAB] OR control*[TIAB] OR volunteer*[TIAB] OR evaluat*[TIAB] OR compar*[TIAB] OR longitudinal[TIAB] OR long-term[TIAB] OR longterm[TIAB] OR case-control*[TIAB] OR case control*[TIAB] OR case referrent*[TIAB] OR case-referrent*[TIAB] OR time series[TIAB] OR time-series[TIAB] OR followup[TIAB] OR follow up[TIAB] OR follow-up[TIAB] OR before-and-after[TIAB] OR before-after[TIAB]) AND (study[TIAB] OR studies[TIAB] OR trial*[TIAB]))
15 Search (((#12)) OR (#13)) OR (#14)
16 Search (((((#1)) AND (#4)) AND (#7)) AND (#11)) AND (#15)

## Table B14. Science Citation Index Expanded (via Web of Science^®^)—ISI Web of Knowledge ver 3.0

Years/issue searched: 1900-present

Limits: 1983-2007; English

Search date: February 22, 2007

Results: 938

1 TS=(infan* OR (baby OR babies) OR toddler* OR child* OR adolescen* OR youth* OR juvenil* OR teen* OR (teen SAME ager*) OR (young SAME person*) OR (young SAME people) OR (young SAME adult*)) OR TS=(pube* OR parent* OR famil* OR caregiv* OR (care SAME giv*) OR caretak* OR (care SAME tak*) OR carer*)
2 TS=((Diabetes SAME mellitus) OR DM) AND TS=((Type SAME 1) OR (Type SAME I)) OR TS=(diabet* OR IDDM) OR TS=((insulin SAME dependent) OR insulindependent OR earl* OR juvenil* OR child* OR labil* OR keto* OR autoimmun* OR (auto SAME immun*) OR (sudden SAME onset)) AND TS=((diabetes SAME mellitus) OR DM)
3 #2 NOT TS=(diabetes SAME insipidus)
4 TS=((education* OR home) SAME (meeting* OR session* OR strateg* OR workshop*OR visit*)) OR TS=(video* OR gam* OR phone OR telephon* OR program* OR interven* OR inform* OR educat*OR teach* OR train* OR instruct*)
5 TS=((Home SAME care) OR TS=(school SAME health) SAME TS=Service*) OR TS=(diabet* SAME diet)
6 TS=(Behav* OR cognit* OR psycho*OR family OR nutrition* OR diet*) AND TS=(therap* OR modif*)
7 TS=Counse?ling OR (TS=(Adolescent OR child) AND TS=psychology)
8 TS=(Patient SAME (Care OR management)) OR TS=(Self SAME help SAME group*) OR TS=(Health OR patient) AND TS=education
9 #8 OR #7 OR #6 OR #5 OR #4
10 TS=(ketoacido* OR keto same acido*) OR TS=DKA OR TS=SMBG OR TS=(blood SAME glucose) OR TS=BG OR TS=((metabolic OR diabet* OR glyc?emic OR glucose) SAME control) OR TS=(HbA1c OR A1c OR HbA1 OR GHb OR hemoglobin OR haemoglobin)
11 TS=(self SAME (care OR regulat* OR monitor* OR manage* OR efficacy)) OR TS=(attitud* OR behavior* OR complian* OR adheren* OR improv* OR chang* OR cope OR coping OR skill* OR knowledge OR learn* OR cognition)
12 TS=(Program SAME evaluation) OR TS=(Treatment SAME Outcome) OR TS=(problem SAME solving) OR TS=((effect* OR impact OR evaluat* OR compar*) SAME (treatment OR care) SAME program*) OR TS=“quality of life” OR TS=hospitali?ation OR TS=admission* OR TS=(service SAME utilization)
13 #12 OR #11 OR #10
14 TS=(randomized controlled trial* OR controlled clinical trial* OR research design OR placebo* OR random* OR pre test* OR prettest* OR post test* OR posttest* ) OR TS=(observation* OR prospectiv* OR cohort* OR control* OR volunteer* OR evaluat* OR compar* OR intervention OR longitudinal OR long term OR long-term OR longterm OR “case control*” OR case-control* OR “time series” OR time-series OR “case referent” OR case-referent OR before-and-after OR before-after OR followup OR “follow up” OR follow-up) AND TS=(study OR studies OR trial*) NOT TS=animal*
15 #9 AND #3 AND #1
16 #15 AND #14 AND #13

## Table B15. SSCI-Expanded (Social Science Citation Index) (Expanded via Web of Science^®^)—ISI Web of Knowledge ver 3.0

Years/issue searched: 1956-present

Limits: English; 1983-present

Search date: February 22, 2007

Results: 250

1 TS=(infan* OR (baby OR babies) OR toddler* OR child* OR adolescen* OR youth* OR juvenil* OR teen* OR (teen SAME ager*) OR (young SAME person*) OR (young SAME people) OR (young SAME adult*)) OR TS=(pube* OR parent* OR famil* OR caregiv* OR (care SAME giv*) OR caretak* OR (care SAME tak*) OR carer*)
2 TS=((Diabetes SAME mellitus) OR DM) AND TS=((Type SAME 1) OR (Type SAME I)) OR TS=(diabet* OR IDDM) OR TS=((insulin SAME dependent) OR insulindependent OR earl* OR juvenil* OR child* OR labil* OR keto* OR autoimmun* OR (auto SAME immun*) OR (sudden SAME onset)) AND TS=((diabetes SAME mellitus) OR DM)
3 #2 NOT TS=(diabetes SAME insipidus)
4 TS=((education* OR home) SAME (meeting* OR session* OR strateg* OR workshop*OR visit*)) OR TS=(video* OR gam* OR phone OR telephon* OR program* OR interven* OR inform* OR educat*OR teach* OR train* OR instruct*)
5 TS=((Home SAME care) OR TS=(school SAME health) SAME TS=Service*) OR TS=(diabet* SAME diet)
6 TS=(Behav* OR cognit* OR psycho*OR family OR nutrition* OR diet*) AND TS=(therap* OR modif*)
7 TS=Counse?ling OR (TS=(Adolescent OR child) AND TS=psychology)
8 TS=(Patient SAME (Care OR management)) OR TS=(Self SAME help SAME group*) OR TS=(Health OR patient) AND TS=education
9 #8 OR #7 OR #6 OR #5 OR #4
10 TS=(ketoacido* OR keto same acido*) OR TS=DKA OR TS=SMBG OR TS=(blood SAME glucose) OR TS=BG OR TS=((metabolic OR diabet* OR glyc?emic OR glucose) SAME control) OR TS=(HbA1c OR A1c OR HbA1 OR GHb OR hemoglobin OR haemoglobin)
11 TS=(self SAME (care OR regulat* OR monitor* OR manage* OR efficacy)) OR TS=(attitud* OR behavior* OR complian* OR adheren* OR improv* OR chang* OR cope OR coping OR skill* OR knowledge OR learn* OR cognition)
12 TS=(Program SAME evaluation) OR TS=(Treatment SAME Outcome) OR TS=(problem SAME solving) OR TS=((effect* OR impact OR evaluat* OR compar*) SAME (treatment OR care) SAME program*) OR TS=“quality of life” OR TS=hospitali?ation OR TS=admission* OR TS=(service SAME utilization)
13 #12 OR #11 OR #10
14 TS=(randomized controlled trial* OR controlled clinical trial* OR research design OR placebo* OR random* OR pre test* OR prettest* OR post test* OR posttest* ) OR TS=(observation* OR prospectiv* OR cohort* OR control* OR volunteer* OR evaluat* OR compar* OR intervention OR longitudinal OR long term OR long-term OR longterm OR “case control*” OR case-control* OR “time series” OR time-series OR “case referent” OR case-referent OR before-and-after OR before-after OR followup OR “follow up” OR follow-up) AND TS=(study OR studies OR trial*) NOT TS=animal*
15 #9 AND #3 AND #1
16 #15 AND #14 AND #13

## Table B16. Dissertations and Theses Full Text ProQuest™

Search date: March 1, 2007

Results: 130

(diabet* AND (type 1 OR type I))) AND (infan* OR child* OR adolescen* OR famil* OR parent* OR caregiv* OR carer) AND NOT (mouse OR mice OR rat* OR cow*)

OVID databases

RCT filter adapted from:

Cochrane Highly Sensitive Search Strategy (2005) Revision from Glanville JM, Lefebvre C, Miles JNV, Camosso-Stefinovic J. How to identify randomized controlled trials in Medline: ten years on. J Med Libr Assoc 2006; 94(2):130–6

Science Citation Index and Social Science Citation Index databases

RCT filter from Lisa Tjosvold (ARCHE) located at http://www.ualberta.ca/ARCHE/filters.html#rctwos

At the recommendation of the TEP panel, the searches were rerun without the study design component. Studies found previously (with the study design filter) were then removed from the search before importing into ProCite. The numbers for “no study design” are the raw results from the search, before removing duplicate studies from the study design results.

## Gray Literature

Table B17. Diabetes organizations and societies

Website | URL
Alberta (Canada) Foundation for Diabetes Research | http://www.afdr.ab.ca
American Association of Diabetes Educators (AADE) | http://www.aadenet.org
American Diabetes Association | http://www.diabetes.org
American Dietetic Association | http://www.eatright.org/cps/rde/xchg/ada/hs.xsl/index.html
American Public Health Association | http://www.apha.org
Australian Diabetes Educators Association (ADEA) | http://www.adea.com.au/index.aspx
Australian Diabetes Society (ADS) | http://www.racp.edu.au/ads
Barbara Davis Center for Childhood Diabetes | http://www.uchsc.edu/misc/diabetes
British Society for Paediatric Endocrinology and Diabetes | http://www.bsped.org.uk
Canadian Diabetes Association (CDA) | http://www.diabetes.ca
Center for Disease Control and Prevention. Diabetes Public Health Resource | http://www.cdc.gov/diabetes
Children's Diabetes Foundation at Denver | http://www.childrensdiabetesfdn.org
Diabetes Action Research and Education Foundation | http://www.diabetesaction.org
Diabetes Education and Camping Association | http://www.diabetescamps.org
Diabetes Care and Education | http://www.dce.org
Diabetes Australia | http://www.diabetesaustralia.com.au
Diabetes India | http://diabetesindia.com
Diabetes New Zealand | http://www.diabetes.org.nz
Diabetes Technology Society | http://www.clinicaldiabetestechnology.org
Diabetes UK | http://www.diabetes.org.uk
Diabetes Exercise and Sports Association | http://www.diabetes-exercise.org
Diabetes Institutes Foundation | http://www.dif.org
Diabetes Research and Wellness Foundation | http://www.diabeteswellness.net
Diabetes Research Institute | http://www.drinet.org
Diabetes Technology Society | http://www.diabetestechnology.org
Dietitians of Canada | http://www.dietitians.ca
European Association for the Study of Diabetes | http://www.easd.org
Federation of European Nurses in Diabetes | http://www.fend.org
Finnish Diabetes Association | http://www.diabetes.fi
Joslin Diabetes Center | http://www.joslin.harvard.edu
International Diabetes Institute | http://www.idi.org.au
International Diabetes Federation | http://www.idf.org
International Society for Pediatric and Adolescent Diabetes (ISPAD) | http://www.ispad.org
Juvenile Diabetes Research Foundation Australia | http://www.jdrf.org.au
Juvenile Diabetes Research Foundation International | http://www.jdf.org
Juvenile Diabetes Research Foundation Canada | http://www.jdfc.ca
Naomi Berrie Diabetes Center | http://nbdiabetes.org
National Diabetes Education Initiative (NDEI) | http://www.ndei.org
Pediatric Endocrinology Nursing Society | http://www.pens.org/all.php?l=home&w=1280

Table B18. Medical professional websites

Website | URL
American Association of Clinical Endocrinologists | http://www.aace.com
American Medical Association | http://www.ama-assn.org
Canadian Medical Association | http://www.cma.ca/index.cfm/ci_id/121/la_id/1.htm
Diabetes for Professionals | http://www.d4pro.com/HomeDefault.asp
Diabetes Prevention and Control Branch | http://www.ncdiabetes.org
Diabetes Research in Children Network (DirecNet) | http://public.direc.net/index.htm
DiabetesIndia.com | http://www.diabetesindia.com
Endocrineindia.com | http://www.endocrineindia.com
Healthcare Professionals (Canadian Diabetes Association) | http://www.diabetes.ca/Section_Professionals/index.asp
National Diabetes Support Team | http://www.diabetes.nhs.uk/
National Institute for Health and Clinical Excellence (NICE) | http://www.nice.org.uk
National Institute of Diabetes and Digestive and Kidney Diseases | http://www2.niddk.nih.gov
ndei (National Diabetes Education Initiative) | http://www.ndei.org
National Glycohemoglobin Standardization Program (NGSP) | http://www.ngsp.org/ngsp.html
Royal College of Nursing | http://www.rcn.org.uk/resources/improvingcare/diabetes/index.php
SEARCH For Diabetes in Youth | http://www.searchfordiabetes.org/public/provider/index.cfm
The Endocrine Society | http://www.endo-society.org
Type 1 Diabetes TrialNet | http://www.diabetestrialnet.org
U.S. Department of Health and Human Services—National Institutes of Health | http://health.nih.gov
U.S. Food and Drug Administration Diabetes Information | http://www.fda.gov/diabetes/
World Health Organization | http://www.who.org

Table B19. Journal websites

Website | URL
Acta Diabetologia | http://link.springer.de/link/service/journals/00592
Annals of Nutrition and Metabolism | http://www.karger.ch/journal/anm
Annual Review of Nutrition | http://nutr.annualreviews.org
Asia Pacific Journal of Clinical Nutrition | http://www.healthyeatingclub.com/APJCN/index.htm
Australian Journal of Nutrition and Dietetics | http://www.ajnd.org.au
British Journal of Nutrition | http://journals.cambridge.org/action/displayJournal?jid=BJN
Canadian Journal of Diabetes | http://www.diabetes.ca/Section_Professionals/pub_cjd.asp
Canadian Journal of Dietetic Practice and Research | http://dcjournal.metapress.com/home/main.mpx
Clinical Diabetes | http://clinical.diabetesjournals.org
Clinical Nutrition | http://www.harcourt-international.com/journals/clnu
Current Diabetes Reports | http://www.biomedcentral.com/currdiabetesrep
Current Opinion in Clinical Nutrition and Metabolic Care | http://www.co-clinicalnutrition.com
Diabetes | http://diabetes.diabetesjournals.org
Diabetes | http://www.diabetes.org/Diabetes
Diabetes and Primary Care | http://www.sbcommunicationsgroup.com/publications/diabetesprimarycare/archive.htm
Diabetes Care | http://care.diabetesjournals.org
Diabetes Digest | http://www.diabetesdigest.com
Diabetes Forecast | http://www.diabetes.org/DiabetesForecast
Diabetes Metabolism Research and Reviews | http://www3.interscience.wiley.com/cgi-bin/jhome/10009394
Diabetes Research and Clinical Practice | http://www.sciencedirect.com/science/journal/01688227
Diabetes Self-Management Magazine | http://www.diabetes-self-mgmt.com
Diabetes Spectrum | http://www.diabetes.org/DiabetesSpectrum
Diabetes Technology and Therapeutics | http://www.liebertonline.com/dia?cookieSet=1
Diabetes, Obesity and Metabolism | http://www.blackwellpublishing.com/journal.asp
Diabetes/Metabolism Reviews | http://www3.interscience.wiley.com/cgi-bin/jhome/3666?CRETRY=1&SRETRY=0
Diabetic Medicine | http://www.blackwellpublishing.com/journal.asp?ref=0742-3071&site=1
Diabetologia | http://link.springer.de/link/service/journals/00125/index.htm
Disease Management | http://www.liebertonline.com/dis
DOC News | http://docnews.diabetesjournals.org
eCMAJ | http://www.collectionscanada.ca/eppp-archive/100/201/300/cdn_medical_association/cmaj/index.asp
European Journal of Clinical Nutrition | http://www.nature.com/ejcn/index.html
European Journal of Nutrition | http://www.steinkopff.springer.de/journal/394
Indian Journal of Biochemistry and Biophysics | http://www.niscair.res.in/ScienceCommunication/ResearchJournals/rejour/ijbb/ijbb0.asp
Indian Journal of Medical Research | http://www.icmr.nic.in/ijmr/ijmr.htm
Indian Journal of Medical Sciences | http://www.bioline.org.br/ms
International Journal of Diabetes and Metabolism | http://ijod.uaeu.ac.ae
Journal of Diabetes and its Complications | http://www.sciencedirect.com/science/journal/10568727
Journal of Diabetes Science and Technology | http://www.journalofdst.org
Journal of Diabetic Nursing | http://www.sbcommunicationsgroup.com/publications/diabetesnursing/archive.htm
Journal of the American Dietetic Association | http://www.adajournal.org
Journal of the Association of Physicians of India | http://japi.org/index.asp
Pediatric Diabetes | http://www.blackwell-synergy.com/loi/PDI
Public Health Nutrition | http://www.cabi-publishing.org/journals.phn
Review of Diabetic Studies | http://www.soc-bdr.org/content/e4/e887/volRdsVolumes4215/issRdsIssues4216/index_en.html
The American Journal of Clinical Nutrition | http://www.ajcn.org
Tufts University Health and Nutrition Letter | http://healthletter.tufts.edu/