# Appendix A. Technical Expert Panel and Peer Reviewers

## Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives are sought. Divergent and conflicting opinions are common and perceived as health scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

Technical Expert | Affiliations/Location
Denis Daneman, M.B., B.Ch., F.R.C.P.C. | University of Toronto and Hospital for Sick Children Toronto, ON
Alison B. Evert, M.S., R.D., C.D.E. | Diabetes Care Center, University of Washington Medical Center Seattle, WA
Jeffrey Johnson, B.S.P., M.S., Ph.D. | University of Alberta Edmonton, AB
Richard A. Justman, M.D. | United HealthCare Edina, MN
Lori M. B. Laffel, B.S., M.D., M.P.H. | Joslin Diabetes Center Boston, MA
Gabriela Ramírez-Garnica, Ph.D., M.P.H. | Nemours Children's Clinic Orlando, FL
Janet Silverstein, M.D. | University of Florida Gainesville, FL

## Peer Reviewers

Peer reviewer comments on a preliminary draft of this report were considered by the EPC in preparation of this final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

Technical Expert | Affiliations/Location
William L. Clarke, M.D., F.A.A.P. | University of Virginia Health System Charlottesville, VA
Nathaniel Clark, M.D., F.A.A.P. | Novo Nordisk, Inc. Princeton, NJ
Debra Counts, M.D., F.A.A.P. | University of Maryland Baltimore, MD
Marion J. Franz, M.S., R.D., L.D., C.D.E. | Nutrition Concepts by Franz, Inc. Minneapolis, MN
Stephen J. Spann, M.D., M.B.A. | Baylor College of Medicine Houston, TX
Randi Streisand, Ph.D., C.D.E. | Children's National Medical Center Washington, DC
Dorothy Becker, M.B., B.Ch. | Children's Hospital of Pittsburgh Pittsburgh, PA