# References and Included Studies

1 Haller MJ, Atkinson MA, Schatz D. (2005). Type 1 diabetes mellitus: etiology, presentation, and management. Pediatr Clin North Am.
2 National Diabetes Education Program. Overview of diabetes in children and adolescents: a fact sheet from the National Diabetes Education Program [web page]. Available at: http://ndep.nih.gov/diabetes/youth/youth_FS.htm. Accessed Dec8,2006.
3 Diabetes Control and Complications Research Group. (1994). Diabetes Control and Complications Trial (DCCT): update. Diabetes Care.
4 Gage H, Hampson S, Skinner TC, et al. (2004). Educational and psychosocial programmes for adolescents with diabetes: approaches, outcomes and cost-effectiveness. Patient Educ Couns.
5 Anderson BJ, Brackett J, Ho J, et al. (1999). An office-based intervention to maintain parent-adolescent teamwork in diabetes management. Impact on parent involvement, family conflict, and subsequent glycemic control. Diabetes Care.
6 Anderson BJ, Wolf FM, Burkhart MT, et al. (1989). Effect of peer-group intervention on metabolic control of adolescents with IDDM. Randomized outpatient study. Diabetes Care.
7 Barglow P. (1983). Diabetic control in children and adolescents: psychosocial factors and therapeutic efficacy. J Youth Adolesc.
8 Boardway RH, Delamater AM, Tomakowsky J, et al. (1993). Stress management training for adolescents with diabetes. J Pediatr Psychol.
9 Brown SJ, Lieberman D, Germeny B, et al. (1997). Educational video game for juvenile diabetes: results of a controlled trial. Medical informatics = Medecine et informatique.
10 Campaigne BN, et al. (1985). The effects of physical training on blood lipid profiles in adolescents with insulin-dependent diabetes mellitus. Phys Sportsmed.
11 Caravalho JY, Saylor CR. Continuum of care. An evaluation of a nurse case-managed program for children with diabetes. Pediatr Nurs 2000;26(3): 296–300, 328.
12 Christensen NK, King EB, Prestwich L. (2000). Diabetes education evaluation. Top Clin Nutr.
13 Cigrang JA. Psychosocial intervention for youth with insulin-dependent diabetes: a study of the metabolic and psychosocial effects of group therapy [dissertation]. Tennessee: Memphis State University; 1991.
14 Couper JJ, Taylor J, Fotheringham M, et al. (1999). Failure to maintain the benefits of home-based intervention in adolescents with poorly controlled type I diabetes. Diabetes Care.
15 Coupland KJ. The effects of a family-based intervention on regimen adherence and metabolic control of adolescents with IDDM: a randomized controlled outcome study [dissertation]. Ontario: University of Ottawa; 1990.
16 Delamater AM, Smith JA, Bubb J, et al. Family-based behavior therapy for diabetic adolescents. In: Johnson JH, Johnson SB, eds. Advances in child health psychology. Gainesville, FL: J Hillis Miller Health Science Center; 1991. p. 293–306.
17 Delamater AM, Bubb J, Davis SG, et al. (1990). Randomized prospective study of self-management training with newly diagnosed diabetic children. Diabetes Care.
18 Dougherty G, Schiffrin A, White D, et al. (1999). Home-based management can achieve intensification cost-effectively in type I diabetes. Pediatrics.
19 Golden MP, Russell BP, Ingersoll GM, et al. (1985). Management of diabetes mellitus in children younger than 5 years of age. Am J Dis Child.
20 Greco P, Pendley JS, McDonell K, et al. (2001). A peer group intervention for adolescents with type 1 diabetes and their best friends. J Pediatr Psychol.
21 Grey M, Boland E, Davidson M, et al. (2000). Coping skills training for youth with diabetes mellitus has long-lasting effects on metabolic control and quality of life. J Pediatr.
22 Gross AM, Magalnick LJ, Richardson P. (1985). Self-management training with families of insulin-dependent diabetic children: a controlled long-term investigation. Child Fam Behav Ther.
23 Gross AM, Heimann L, Shapiro R, et al. (1983). Children with diabetes. Social skills training and hemoglobin A1c levels. Behav Modif.
24 Hackett AF, Court S, Matthews JNS, et al. (1989). Do education groups help diabetics and their parents. Arch Dis Child.
25 Hains A, Davies WH, Parton E, et al. (2000). A stress management intervention for adolescents with type 1 diabetes. Diabetes Educ.
26 Hakimi M. Psychosocial adaptation following the diagnosis of insulin-dependent diabetes mellitus: an intervention [dissertation]. District of Columbia: The George Washington University; 1998.
27 Harkavy J, Johnson SB, Silverstein J, et al. (1983). Who learns what at diabetes summer camp. J Pediatr Psychol.
28 Harris M, Harris BS, Mertlich D. (2005). Brief report: in-home family therapy for adolescents with poorly controlled diabetes: failure to maintain benefits at 6-month follow-up. J Pediatr Psychol.
29 Hill E, Sibthorp J. (2006). Autonomy support at diabetes camp: a self determination theory approach to therapeutic recreation. Ther Recreation J.
30 Hoff AL, Mullins LL, Gillaspy SR, et al. (2005). An intervention to decrease uncertainly and distress among parents of children newly diagnosed with diabetes: a pilot study. Families Systems & Health.
31 Horan PP, Yarborough MC, Besigel G, et al. (1990). Computer-assisted self-control of diabetes by adolescents. Diabetes Educ.
32 Howe CJ, Jawad AF, Tuttle AK, et al. (2005). Education and telephone case management for children with type 1 diabetes: a randomized controlled trial. J Pediatr Nurs.
33 Kaplan RM, Chadwick MW, Schimmel LE. (1985). Social learning intervention to promote metabolic control in type I diabetes mellitus: pilot experiment results. Diabetes Care.
34 Karaguzel G, Bircan I, Erisir S, et al. (2005). Metabolic control and educational status in children with type 1 diabetes: effects of a summer camp and intensive insulin treatment. Acta Diabetol.
35 Kemp SF, Canfield ME, Kearns FS, et al. (1986). The effect of short-term intervention on long-term diabetes management. J Ark Med Soc.
36 Kennedy-Iwai RA. The effects of communication training with parents of newly diagnosed diabetic children [dissertation]. Arizona: Arizona State University; 1991.
37 Koontz AD. A mission-based program evaluation and outcome study of a diabetes summer camp [dissertation]. Kansas: University of Kansas; 2001.
38 Laffel LMB, Vangsness L, Connell A, et al. (2003). Impact of ambulatory family-focused teamwork intervention on glycemic control in youth with type 1 diabetes. J Pediatr.
39 Lawson ML, Frank MR, Fry MK, et al. (2000). Intensive diabetes management in adolescents with type 1 diabetes: the importance of intensive follow-up. J Pediatr Endocrinol.
40 Likitmaskul S, Wekawanich J, Wongarn R, et al. (2002). Intensive diabetes education program and multidisciplinary team approach in management of newly diagnosed type 1 diabetes mellitus: a greater patient benefit, experience at Siriraj Hospital. J Med Assoc Thai.
41 Lipman TH. (1988). Length of hospitalization of children with diabetes: effect of a clinical nurse specialist. Diabetes Educ.
42 Lucey D, Wing E. (1985). A clinic based educational programme for children with diabetes. Diabet Med.
43 Mann NP, Noronha JL, Johnston DI. (1984). A prospective study to evaluate the benefits of long-term self-monitoring of blood glucose in diabetic children. Diabetes Care.
44 Marteau TM, Gillespie C, Swift PG. (1987). Evaluation of a weekend group for parents of children with diabetes. Diabet Med.
45 Mason DL. The development of a board game on self management of diabetes mellitus for children with type I diabetes (health, chronic disease) [dissertation]. Pennsylvania: Temple University; 1986.
46 Massouh SR, Steele TM, Alseth ER, et al. (1989). The effect of social learning intervention on metabolic control of insulin-dependent diabetes mellitus in adolescents. Diabetes Educ.
47 McNabb WL, Quinn MT, Murphy DM, et al. (1994). Increasing children's responsibility for diabetes self-care: the in control study. Diabetes Educ.
48 Mendez FJ, Belendez M. (1997). Effects of a behavioral intervention on treatment adherence and stress management in adolescents with IDDM. Diabetes Care.
49 Mitchell B. (1996). The effects of an early intervention strategy in improving the adjustment to diabetes in children. Canadian Journal of Diabetes Care.
50 Monaco L, Geffken G, Silverstein JH. (1996). Accuracy of injection site identification among children with insulin dependent diabetes mellitus: a comparison of traditional and new visual aids. Clin Pediatr (Phila).
51 Moran G, Fonagy P, Kurtz A, et al. (1991). A controlled study of the psychoanalytic treatment of brittle diabetes. J Am Acad Child Adolesc Psychiatry.
52 Nordfeldt S, Johansson C, Carlsson E, et al. (2005). Persistent effects of a pedagogical device targeted at prevention of severe hypoglycaemia: a randomized, controlled study. Acta Paediatr.
53 Nordfeldt S, Ludvigsson J. (2002). Self-study material to prevent severe hypoglycaemia in children and adolescents with type 1 diabetes. A prospective intervention study. Practical Diabetes International.
54 Nordfeldt S, Ludvigsson J. (1999). Adverse events in intensively treated children and adolescents with type 1 diabetes. Acta Paediatr.
55 Nunn E, King B, Smart C, et al. (2006). A randomized controlled trial of telephone calls to young patients with poorly controlled type 1 diabetes. Pediatr Diabetes.
56 Olmsted MP, Daneman D, Rydall AC, et al. (2002). The effects of psychoeducation on disturbed eating attitudes and behavior in young women with type 1 diabetes mellitus. Int J Eat Disord.
57 Panagiotopoulos C, Preston JM, Stewart LL, et al. (2003). Weekly telephone contact by a diabetes educator in adolescents with type 1 diabetes. Canadian Journal of Diabetes.
58 Pichert JW, Smeltzer C, Snyder GM, et al. (1994a). Traditional vs anchored instruction for diabetes-related nutritional knowledge, skills, and behavior. Diabetes Educ.
59 Pichert JW, Snyder GM, Kinzer CK, et al. (1994b). Problem solving anchored instruction about sick days for adolescents with diabetes. Patient Educ Couns.
60 Pichert JW, Murkin SA, Snyder GM, et al. (1993). Problem-based diabetes education using a video anchor. Diabetes Spectrum.
61 Povlsen L, Olsen B, Ladelund S. (2005). Educating families from ethnic minorities in type 1 diabetes—experiences from a Danish intervention study. Patient Educ Couns.
62 Remley DT. The impact of diabetes camping experiences on direct and mediating diabetes management outcomes [dissertation]. Kentucky: University of Kentucky; 1999.
63 Satin W, Greca AM, Skyler JS. (1989). Diabetes in adolescence: effects of multifamily group intervention and parent simulation of diabetes. J Pediatr Psychol.
64 Schlundt DG, Rea M, Hodge M, et al. (1996). Assessing and overcoming situational obstacles to dietary adherence in adolescents with IDDM. J Adolesc Health.
65 Shobhana R, Rama RP, Vijay V, et al. (1997). Diabetes education session for young IDDM probands and their family members in a developing country: an evaluation. Practical Diabetes International.
66 Siminerio LM, Charron PD, Banion C, et al. (1999). Comparing outpatient and inpatient diabetes education for newly diagnosed pediatric patients. Diabetes Educ.
67 Smith KE, Schreiner B, Jackson C, et al. (1993). Teaching assertive communication skills to adolescents with diabetes: evaluation of a camp curriculum. Diabetes Educ.
68 Smith KE, Schreiner BJ, Brouhard BH, et al. (1991). Impact of a camp experience on choice of coping strategies by adolescents with insulin-dependent diabetes mellitus. Diabetes Educ.
69 Srinivasan S, Craig ME, Beeney L, et al. (2004). An ambulatory stabilisation program for children with newly diagnosed type 1 diabetes. Med J Aust.
70 Sundelin J, Forsander G, Mattson SE. (1996). Family-oriented support at the onset of diabetes mellitus: a comparison of two group conditions during 2 years following diagnosis. Acta Paediatr.
71 Svoren BM, Butler D, Levine BS, et al. (2003). Reducing acute adverse outcomes in youths with type 1 diabetes: a randomized, controlled trial. Pediatrics.
72 Szumowski E. A family-oriented developmental and behavioral intervention to increase adherence by diabetic children to their treatment regimens [dissertation]. Pennsylvania: University of Pittsburgh; 1990.
73 Templeton CL, Burkhart MT, Anderson BJ, et al. (1988). A group approach to nutritional problem solving using self-monitoring of blood glucose with diabetic adolescents. Diabetes Educ.
74 Thomas-Dobersen DA, Butler SN, Fleshner M. (1993). Evaluation of a weight management intervention program in adolescents with insulin-dependent diabetes mellitus. J Am Diet Assoc.
75 Verrotti A, Chiarelli F, Sabatino G, et al. (1993). Education, knowledge and metabolic control in children with type 1 diabetes. Riv Eur Sci Med Farmacol.
76 Viner RM, Christie D, Taylor V, et al. (2003). Motivational/solution-focused intervention improves HbA1c in adolescents with Type 1 diabetes: a pilot study. Diabet Med.
77 von Sengbusch S, Muller GE, Hager S, et al. (2006). Mobile diabetes education and care: intervention for children and young people with Type 1 diabetes in rural areas of northern Germany. Diabet Med.
78 Vyas S, Mullee M, Kinmonth AL. (1988). British Diabetic Association holidays—what are they worth?. Diabet Med.
79 Wadham C, Hassler Hurst J, Almond J, et al. (2005). Integrating group education into paediatric diabetes care: FACTS. Journal of Diabetes Nursing.
80 Webb PM. The impact of parental involvement in goal setting on treatment adherence for children with insulin-dependent diabetes mellitus [dissertation]. Indiana: Purdue University; 1999.
81 Wolanski R, Sigman T, Polychronakos C. (1996). Assessment of blood glucose self-monitoring skills in a camp for diabetic children: the effects of individualized feedback counselling. Patient Educ Couns.
82 Wysocki T, Harris MA, Buckloh LM, et al. (2007). Randomized trial of behavioral family systems therapy for diabetes: maintenance of effects on diabetes outcomes in adolescents. Diabetes Care.
83 Wysocki T, Harris M, Greco P, et al. (2000). Randomized, controlled trial of behavior therapy for families of adolescents with insulin-dependent diabetes mellitus. J Pediatr Psychol.
84 Zorumski CH. The effects of self-care training on the self-concept self-care behavior, and metabolic control of diabetic children [dissertation]. Virginia: College of William and Mary; 1997.
85 Libman I, Songer T, LaPorte R. (1993). How many people in the U.S. have IDDM?. Diabetes Care.
86 Liese AD, D'Agostino RB, Hamman RF, et al. (2006). The burden of diabetes mellitus among US youth: prevalence estimates from the SEARCH for Diabetes in Youth Study. Pediatrics.
87 Crawford JM. Liver, biliary tract, and pancreas. In: Robbins SL, Cotran RS, Kumar V Pocket companion to Robbins pathologic basis of disease. Philadelphia, PA: WB Saunders; 1991. p. 313–7.
88 Wolever TM, Hamad S, Chiasson JL, et al. (1999). Day-to-day consistency in amount and source of carbohydrate associated with improved blood glucose control in type 1 diabetes. J Am Coll Nutr.
89 Schoenle EJ, Schoenle D, Molinari L, et al. (2002). Impaired intellectual development in children with Type I diabetes: association with HbA(1c), age at diagnosis and sex. Diabetologia.
90 Goldstein D, England J, Hess R, et al. (1981). A prospective study of symptomatic hypoglycaemia in young diabetic patients. Diabetes Care.
91 Glastras SJ, Mohsin F, Donaghue KC. (2005). Complications of diabetes mellitus in childhood. Pediatr Clin North Am.
92 Donaghue KC, Fairchild JM, Craig ME, et al. (2003). Do all prepubertal years of diabetes duration contribute equally to diabetes complications?. Diabetes Care.
93 Finne P, Reunanen A, Stenman S, et al. (2005). Incidence of end-stage renal disease in patients with type 1 diabetes. JAMA.
94 Pambianco G, Costacou T, Ellis D, et al. (2006). The 30-year natural history of type 1 diabetes complications: the Pittsburgh Epidemiology of Diabetes Complications Study experience. Diabetes.
95 American Diabetes Association. (2006). Standards of medical care in diabetes, 2006. Diabetes Care.
96 Mensing C, Boucher J, Cypress M, et al. (2006). National standards for diabetes self-management education. Diabetes Care.
97 Gehling E. (2001). Medical nutrition therapy: an individualized approach to treating diabetes. Lippincotts Case Manag.
98 The Diabetes Control and Complications Trial Research Group. (1993). The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. N Engl J Med.
99 Hampson SE, Skinner TC, Hart J, et al. (2001). Effects of educational and psychosocial interventions for adolescents with diabetes mellitus: a systematic review. Health Technol Assess.
100 Winkley K, Ismail K, Landau S, et al. (2006). Psychological interventions to improve glycaemic control in patients with type 1 diabetes: systematic review and meta-analysis of randomised controlled trials. BMJ.
101 Jadad AR, Moore RA, Carroll D, et al. (1996). Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials.
102 Schulz KF, Chalmers I, Hayes RJ, et al. (1995). Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA.
103 Altman D, Schulz K. (2001). Concealing treatment allocation in randomised trials. Br Med J.
104 Cho MK, Bero LA. (1996). The quality of drug studies published in symposium proceedings. Ann Int Med.
105 Thomas BH, Ciliska D, Dobbins M, et al. (2004). A process for systematically reviewing the literature: providing the research evidence for public health nursing interventions. Worldviews Evid Based Nurs.
106 Effective Public Health Practice Project. Dictionary for the effective public health practice project quality assessment tool for quantitative studies [web page]. Available at: http://www.myhamilton.ca/NR/rdonlyres/6BC5E4A7-3F82-41F0-BCE1-6CC9921FDD8A/0/QADictionary2003.pdf. Accessed Feb22,2007.
107 Effective Public Health Practice Project. Quality assessment tool for quantitative studies [web page]. Available at: http://www.myhamilton.ca/NR/rdonlyres/04A24EBE-2C46-411D-AEBA-95A60FDEF5CA/0/QualityTool2003.pdf. Accessed Feb22,2007.
108 Atkins D, Briss PA, Eccles M, et al. (2005). Systems for grading the quality of evidence and the strength of recommendations II: pilot study of a new system. BMC Health Serv Res.
109 Atkins D, Best D, Briss PA, et al. (2004). Grading quality of evidence and strength of recommendations. Br Med J.
110 Guyatt G, Vist G, Falck-Ytter Y, et al. (2006). An emerging consensus on grading recommendations?. ACP J Club.
111 Follmann D, Elliott P, Suh I, et al. (1992). Variance imputation for overviews of clinical trials with continuous response. J Clin Epidemiol.
112 Deeks JJ, Higgins JPT, Altman DGe. Analysing and presenting results. Cochrane Handbook for Systematic Reviews of Interventions 4.2.6. 2006. p. 97–165.
113 DerSimonian R, Laird N. (1986). Meta-analysis in clinical trials. Control Clin Trials.
114 Higgins JPT, Thompson SG. (2002). Quantifying heterogeneity in a meta-analysis. Stat Med.
115 Begg CB, Mazumdar M. (1994). Operating characteristics of a rank correlation test for publication bias. Biometrics.
116 Egger M, Smith GD, Schneider M, et al. (1997). Bias in meta-analysis detected by a simple, graphical test. Br Med J.
117 Duval SJ, Tweedie RL. (2000). A non-parametric “Trim and Fill” method of accounting for publication bias in meta-analysis. JASA.
118 Grey M. (2000). Interventions for children with diabetes and their families. Ann Rev Nurs Res.
119 Diabetes program teaches kids to be case managers. Disease State Management 1997;3(11):138–40.
120 Remley D, Cook NM. Nutrition update. Meal planning self-efficacy index for adolescents with diabetes. Diabetes Educ 1999;25(6): 883–4, 886, 888–90.
121 Whitehead WE. (2004). Control groups appropriate for behavioral interventions. Gastroenterology.
122 Rains JC, Penzien DB. (2005). Behavioral research and the double-blind placebo-controlled methodology: challenges in applying the biomedical standard to behavioral headache research. Headache.