# 4 Discussion

## Grading the Body of Evidence

We assessed the body of evidence for six key outcomes based on five domains: study design, study quality, consistency of effect estimates across studies, precision of effect estimates, and directness of the link between interventions and outcomes (Table 22). For each outcome, the majority of the studies used an RCT design, which is considered the strongest design; however, the quality of the studies was generally low. There was no consistency of effect estimates across studies for the outcomes. Precision was difficult to evaluate as confidence intervals or exact p values were not reported. The link between interventions and outcomes was often difficult to determine. Most interventions had multiple components and, while there may be a correlation between the entire intervention and the outcome, the association between specific intervention components and the outcomes was not evident. We classified the strength of evidence as low, meaning that there is low confidence in the estimate of effect and further research is likely to change our confidence in the estimate of effect.

Table 22 Grading the strength of evidence

Outcome | Design | Quality | Consistency | Precision | Directness | GRADE
HbA1c (n = 52) | RCT = 33 CCT = 7 Cohort = 4 B-A = 8 | Low | No significant effect in 22/52 studies Effect for both IG and CG; change or difference NS in 13/52 IG improved more in 17/52 | Unable to evaluate | Uncertainty about directness | Low
Short-term complications (n = 15) | RCT = 6 CCT = 1 Cohort = 2 B-A = 6 | Low | No significant effect in 7/15 Effect for both IG and CG; change or difference NS in 1/15 IG improved more in 5/15 Improvement made post intervention in 2/15 (B-A) | Unable to evaluate | Uncertainty about directness | Low
Knowledge (n = 29) | RCT = 10 CCT = 6 Cohort = 2 B-A = 11 | Low | No significant effect in 8/29 Intervention group improved more in 4/29 Effect for both IG and CG; change or difference NS in 2/29 Improvements made post intervention in 9/29 (B-A) Results vary between outcome or time point 6/29 | Unable to evaluate | Uncertainty about directness | Low
Self-management skills (n = 21) | RCT = 15 CCT = 3 Cohort = 1 B-A = 2 | Low | No significant effect in 11/21 Intervention group improved more in 7/21 Results vary between outcome or time point in 3/21 | Unable to evaluate | Uncertainty about directness | Low
Coping (n = 14) | RCT = 7 CCT = 1 Cohort = 2 B-A = 4 | Low | No significant effect in 10/14 studies Intervention group improved more in 2/14 Results varied between outcomes in 2/14 | Unable to evaluate | Uncertainty about directness | Low
Quality of Life (n = 4) | RCT = 2 B-A = 2 | Low | No significant effect in 1/4 IG improved more in 1/4 Improvements made post intervention in 2/4 (B-A) | Unable to evaluate | Uncertainty about directness | Low

B-A = uncontrolled before and after study; CG = control group; CCT = controlled clinical trial; IG = intervention group; NS = not significant; RCT = randomized controlled trial

### Quality of the Evidence

Although the majority of included studies were RCTs or CCTs, all but four RCTs obtained a low methodological score of 0, 1 or 2 of a possible 5 points on the Jadad scale, or 0 or 1 out of a possible 3 on the modified Jadad scale. These studies were considered of poor quality with serious threats to internal validity. The primary reason for the low scores was the lack of double blinding in these trials. It is important to recognize that it may not be appropriate to evaluate non-pharmacological interventions by the same standards applied to pharmacological interventions. Although there has been some debate as to whether the lack of double blinding is a serious flaw in studies that examine behavioral interventions,^121,122^ research has shown that there is a potential for performance bias in outcome assessment and studies that are not double blinded can overestimate treatment effects by 17 percent.^102^ Notwithstanding the evidence confirming the importance of double blinding in trials, we conducted a post hoc assessment to identify trials that used single blinding, in particular the blinding of outcome assessors. In 27 percent of the trials, steps had been taken to reduce the potential for measurement bias. While implementing blinding in an RCT of non-pharmacological interventions often requires creative solutions, approaches such as blinding participants to the hypothesis of the study or blinding of outcome assessors have been increasingly adopted. The approaches are ethically justified provided that stringent criteria for protecting research participants are satisfied. Further research in this domain is warranted.

Additionally, 25 percent of included studies were uncontrolled-before-and-after studies, which is not considered to be a rigorous study design because of the difficulty in determining whether any observed effects are solely accounted for by the intervention.

### Consistency of the Evidence

Many of the interventions did not have consistent effects across the intervention (for example, all cognitive behavioral therapy studies did not display the same effect ) or coherent effects across all outcomes (e.g., all studies that showed a statistically significant effect in HbA1c did not necessarily find an effect in any other outcome).

Types of interventions. Diabetes education is a general term that encompasses a wide variety of interventions. Even within categories of the same type of intervention (e.g., cognitive behavioral therapy) there were many differences among studies in the focus of the intervention (e.g., stress management, coping strategies), the mode of delivery, the intensity of the intervention, whether the program was delivered to parents, children or both, and the times at which endpoints were measured. Although we were able to assign interventions to broad categories, there was still a high level of heterogeneity within categories. For example, the general diabetes education category included interventions delivered in such diverse formats as phone calls, small group sessions, educational leaflets, or video games. In addition to considerable heterogeneity, many of the studies had short study length (1 day to 2 weeks) and/or followup, which may not have been enough time to see significant changes. In some studies that showed positive effects, more intense followup of participants or the presence of an experienced team and an intensive management protocol may have been a factor in their success.

Types of control groups. Most of the trials that used control groups described the comparison intervention as “standard care”. Although some studies provided a description of standard care, the content of the education delivered to the control group was rarely detailed. Because the control group would be unlikely to receive “no education”, it is important to understand how the intervention and control interventions differed. Only then will we be able to isolate the factors that make education effective. Furthermore, if standard care is the comparison, researchers should be encouraged to change only one or two elements of an education program during their trial in order to better assess which components are effective and which are not. For example, this was successful, in the coping skills training intervention by Grey et al.

Types of populations. We considered three main population groups: the maintenance population of children with diabetes, which was our “general” category; children with newly diagnosed diabetes receiving their first diabetes treatment and education; and children who had problems achieving optimal metabolic control. In the general population, only a small number of interventions were shown to be effective. Many of these studies took place in academic settings where the patient population may be better educated and established educational programs may already exist. It is possible that these studies did not have sufficient statistical power to detect differences. Furthermore, if children entering these studies already had a certain level of education and motivation, there may be a ceiling effect and the additional education intervention may not have a noticeable impact on knowledge, behavior, or metabolic control. It is possible that these interventions may be effective in different study settings.

In the population of children who were newly diagnosed, a small number of studies compared the delivery of education in inpatient and outpatient settings. While this review did not find that the setting of the education program had an impact on outcomes, the number of studies was small, and there were substantial differences in terms of the specific outpatient setting (e.g., training apartment, day care program) and intensity of intervention. Therefore, it is difficult to state that outpatient settings are as effective as inpatient settings for the delivery of education interventions. Further research controlling for these factors is required.

For children with poorly controlled diabetes, we included studies in this category if the researchers specified that the study population was children with poor metabolic control. However, this allowed for some variability in clinical indicators. For example, the mean HbA1c levels in these studies ranged from 8.2 percent to 14.9 percent. Generally, results in this population were inconclusive, with a small number of studies showing improvement in HbA1c, knowledge and adherence and almost none showing changes in psychosocial outcomes. For the studies that reported improvement in outcomes, there were no common factors; the education interventions fell into different categories and the target populations were defined differently.

Types of outcomes. Our main clinical outcome, HbA1c, was standard across studies. However, for knowledge and psychosocial outcomes there was a wide range assessment tools, ranging from self-designed questionnaires to instruments that were developed and validated for people with diabetes. The use of different tools and metrics, even when measuring the same outcome was an additional factor that made it difficult to pool the results of studies or to generalize the effectiveness of interventions. Use of standardized instruments in studies evaluating outcomes in children with diabetes should alleviate this issue.

## Discussion of Key Questions

There were 80 studies included in this review of diabetes education. Although over 65 percent of the studies were RCTs or CCTs, their methodological quality was generally low. There was considerable heterogeneity with regard to the study population, the educational intervention and the outcomes measured. Furthermore, because most control groups also received some level of education, the studies may not have had sufficient power to detect a clinically or statistically significant difference in the various outcomes examined. These factors make it difficult to draw definitive conclusions and recommendations on the benefits of diabetes education. However, the discussion to follow will address the key questions based on the evidence obtained from the available research.

### 1. What is the evidence that diabetes education on day-to-day management of diabetes improves metabolic control as determined by

HbA1c. HbA1c is the gold standard for assessing diabetes control. The DCCT clearly showed that lower HbA1c leads to a decreased rate of microvascular complications. Therefore, the goal of all diabetes education interventions is to provide the knowledge, skills, and attitude to achieve the lowest HbA1c possible without frequent hypoglycemia. Unfortunately, the results of this review do not indicate that any specific educational intervention leads to consistent and sustained improvement in HbA1c over that achieved with “standard care” education. Cognitive behavioral and family therapy interventions appear to have a clinically significant benefit in some studies, although this was somewhat inconsistent with some studies showing a benefit while others did not. This can be explained in part by the heterogeneity within the intervention categories. Further research should be conducted to confirm these results and test their robustness in other settings.

Although diabetes camps are frequently touted as venues in which education can occur to positively change practices, the main function of these camps seems to be as a vacation and as a support for children and parents. Studies set in diabetes camps are usually of short duration. While they may be successful in terms of participant satisfaction, the results do not suggest any short- or long-term improvement in metabolic control.

Initial management and education of newly diagnosed patients has moved from an inpatient to an outpatient setting in many centers. The results of studies comparing the same education provided in these settings indicate there is no difference in HbA1c up to 2 years after the diagnosis; however, the settings and the interventions were not consistent across the studies and these results should be interpreted cautiously. There are a few individual studies with newly diagnosed patients that demonstrated that education provided by a multidisciplinary team at the time of diagnosis results in improved HbA1c compared to education provided by fewer individuals or at a later time. This comparison needs to be replicated to determine if the benefit is significant.

Patients with poorly controlled diabetes can be major consumers of diabetes health care resources. Numerous studies have examined different interventions to improve HbA1c. Unfortunately, only a few have shown a benefit. More intensive general diabetes education, interventions teaching stress management and coping skills, and family therapy have not been shown to improve diabetes control. Frequent (weekly) contact with motivational interviewing and goal-setting, and individual psychotherapy are interventions that have shown benefit but need to be studied further.

It has been hypothesized that changes in HbA1c may be mediated by changes in knowledge, skills, attitudes and/or behavior. In the 16 studies that measured both knowledge and HbA1c, most groups exhibited improved knowledge after the educational intervention. However, improvements in knowledge did not translate into improved diabetes control. This suggests that lack of knowledge in itself is not necessarily a barrier to improving control.

There were only two studies that measured both skills acquisition and HbA1c and neither showed a correlation between the two outcomes. Likewise, studies that measured psychosocial outcomes and HbA1c (n=24) did not show coherence across outcomes. Results spanned the spectrum from one of the outcomes improving but not the other, to neither outcome improving, and to both outcomes improving. In the studies that showed improvement in both outcomes, two were cognitive behavioral therapy interventions that looked at both self-efficacy and HbA1c, one was a family systems therapy intervention that looked at family relationships and HbA1c, and one was a skills training intervention that examined anxiety and HbA1c. In studies that examined both regimen adherence and HbA1c (n=21), there was little correlation between the outcomes. The two studies that showed improvement in both outcomes were family systems therapy trials. Finally, there was no correlation between outcomes in the four studies that measured quality of life and HbA1c. Based on these results, it is difficult to gain any insight into what is mediating metabolic control. It may be that different issues gain precedence in different families, for example adherence may be important for one family and psychosocial issues for another. Therefore, interventions may need to be targeted to more uniform study populations with similar underlying issues in order to assess the effect of the intervention.

Diabetes-related hospitalizations. Diabetes education appears to be effective in decreasing health care utilization (duration of hospital stay after diagnosis, rate of hospitalization, and ED and physician visits). The education interventions used to achieve this were more intensive, were provided by specialists and multidisciplinary teams, and involved some form of psychotherapy or psychosocial focus. The setting of the intervention (inpatient vs. outpatient) did not have an effect on outcome. Intensive, multidisciplinary interventions may be time- and labor-intensive, but their effect on decreasing health care utilization by patients and families may be quite cost-effective. This would be an interesting and worthwhile future research focus.

Frequency of DKA and hypoglycemia. Results were not as clear in the area of diabetes-related short-term complications. Most studies did not have high enough rates of DKA to show significant differences. Studies reporting on hypoglycemia covered the spectrum of possible outcomes. A possible explanation for this may be that hypoglycemia has so many potential causes. For example, an intervention may target nocturnal hypoglycemia, but not physical activity-related hypoglycemia. It is also possible that standard care and standard diabetes education effectively reduce the incidence of hypoglycemia, making it difficult to demonstrate differences between types of educational interventions.

### 2. What is the evidence that medical nutrition therapy education in day-to-day management of diabetes improves HbA1c values and results in less variability in blood glucose levels?

There is no clear evidence indicating that nutrition therapy education either improves or does not improve diabetes control. We identified only one uncontrolled before-and-after study^12^ that specifically assessed the effect of medical nutrition therapy education on HbA1c. The intervention was delivered to children attending a diabetes camp. The participants' ability to meal-plan and carbohydrate count improved and the improvement in carbohydrate counting correlated with a lower pre-intervention HbA1c. However, none of the other nutrition knowledge scores were correlated with changes in? HbA1c. There were several other studies that described a nutritional education component or module as part of their intervention.^6,^,^9,^,^16,^,^17,^,^24,^,^34,35^ Two of these studies found improved nutritional knowledge or behavior after the intervention^24,35^ but this did not correlate with a lowering of HbA1c in the intervention group. Three studies found improved metabolic control alone.^6,^,^17,34^ The other studies showed no significant changes in HBA1c or regimen adherence.

Studies that reported improvement in HbA1c are disparate in their interventions and designs, and it is difficult to know whether to attribute the improvement to the nutritional therapy component or to the overall change in management^34^ or other components of the intervention.^6^ Because of this heterogeneity, there is no clear evidence indicating that medical nutrition therapy education either improves or does not improve diabetes control and studies are needed to address this question.

### 3. What is the evidence that diabetes education results in improved long-term management of diabetes?

In this review, all but three studies followed participants for 2 years or less. The study with the longest followup tracked hospitalizations for 4 years. Long-term followup in diabetes would generally be considered 5 to 10 years. Therefore, there are no data to determine if a particular educational approach improves long-term control and reduces long-term diabetes complications. Since diabetes management has changed over the years covered by this review and will continue to evolve as more research becomes available, it is unlikely that any study will be able to separate the effect of the educational intervention from the change in diabetes management on the rate of complications. It would be possible, however, for a future review to address the question of which diabetes management strategies improve long-term diabetes control and reduce complications.

### 4. What is the evidence that diabetes education programs improve knowledge about diabetes management?

### a. What is the evidence that this knowledge increases the child's self-confidence in his or her ability to handle the disease and has a positive impact on the child's quality of life (QOL) and other psychosocial issues (e.g., school absences, school performance, adherence to a medical regimen)?

In answering this question we have broken the discussion into sections which will discuss interventions for improving knowledge, skills, and adherence separately from those addressing QOL and other psychosocial issues.

In the majority of studies that were controlled and assessed knowledge there was no difference in knowledge scores between those who received the intervention vs. those who received standard care education. In most studies, patients in both the intervention and control groups demonstrated improved knowledge. A minority of studies using either a cognitive behavioral intervention or general diabetes education delivered at diabetes camp showed a significant difference in knowledge scores in favor of the intervention. Only a few studies addressed interventions to improve skills needed for day-to-day diabetes management. Most interventions in this area resulted in an improvement over standard care. However, the number of studies was small and the interventions and specific skills assessed differed. Several studies addressed issues of self-management and adherence behavior; however, the type of interventions and the measured outcomes were not uniform making it difficult to draw conclusions. It appears that cognitive behavioral therapy may be effective in improving self-care behaviors. In patients with poorly controlled diabetes, there was no specific intervention that was consistently effective, but further studies utilizing family based therapy should be considered. In summay, no clear recommendation can be made regarding a specific educational approach, beyond that as part of standard care, to improve knowledge, skills or self-management behavior.

Most research assessing the effect of diabetes education on psychosocial aspects of diabetes has used controlled study designs (75 percent RCTs and CCTs). However, the heterogeneity in study setting, duration and frequency of intervention, followup period, assessment tools, and primary outcomes, makes it impossible to pool the data. The study results mirror this heterogeneity and span the full spectrum of clinical and statistical significance. There is no particular study design or intervention that demonstrates a consistently positive effect of diabetes education on psychosocial outcomes, including QOL and school performance. However, it is likewise impossible to rule out certain intervention types as ineffective. For instance, cognitive behavioral therapy was effective in improving coping skills in two studies, but was not effective in four others. There are very few studies demonstrating negative effects of education on psychosocial outcomes, but this should be interpreted in light of the known low rate of reporting of negative findings. Even among newly diagnosed children, interventions did not result in significantly improved family and social relationships or support, coping, self-perception, or self-efficacy. Similarly, in children with poor metabolic control, only one of two studies showed a significant improvement in self-efficacy, and one more study showed initial, but not sustained improvement in family and social relationships. The education intervention had no significant effect on family or social support, coping or self-perception among this cohort. Although it seems intuitive that working with patients and families through educational interventions is important, the research does not show a clear effect. One possible explanation for this lack of evidence is that standard care and standard diabetes education used in the control groups may effectively improve psychosocial outcomes, making it difficult to demonstrate differences between groups receiving different types of educational intervention. There are no clear recommendations regarding interventions that are likely to improve psychosocial outcomes.

### b. What is the evidence that this knowledge improves long-term metabolic control (i.e., decreases or prevents diabetes-related complications), as shown in the Diabetes Control and Complications Trial (DCCT) (as measured by retinal, renal, cardiovascular, and neurological evaluations), in children of families who receive these diabetes education or medical nutrition therapy program services compared to children of families who do not receive these services?

We did not identify any studies that addressed this question. There are no studies correlating knowledge and/or a specific educational intervention with long-term diabetes complications. In terms of short-term metabolic control, there were 16 studies that measured some aspect of diabetes knowledge as well as changes in metabolic control as on outcome. In five studies^14,^,^22,^,^34,^,^61,75^ knowledge increased and HbA1c levels decreased post intervention. However, in two of these studies^61,75^ the improvements in metabolic control were not sustained at six and 12 months, respectively. In one study^14^ both HbA1c levels and child's knowledge were not sustained at the 12-month followup. In another study^18^ the intervention group had superior metabolic control. While knowledge increased in both groups and was stable over time, there was no significant difference between the groups. In five studies^9,^,^24,^,^35,^,^72,77^ the significant increase in knowledge did not translate into an improvement in metabolic control. There were five studies^31,^,^32,^,^55,^,^62,69^ in which the intervention did not significantly affect either knowledge or metabolic control. From the studies that measured both these outcomes, one can conclude that an increase in knowledge is not sufficient to bring about behavior changes that improve metabolic control.

### 5. What is the evidence that training in intensive diabetes management (consistent with DCCT, including blood glucose monitoring at least four times a day, three or more daily insulin injections or use of an insulin pump and education on when and how to adjust insulin doses) conducted in the practitioner setting yields

### a. Improved metabolic control, (as determined by HbA1c values, numbers of diabetes-related hospitalizations, frequency of DKA, and numbers of episodes of hypoglycemia)?

Although several studies have reported improved diabetes control in children and adolescents following initiation of intensive diabetes management, only three studies described the educational component or compared different educational interventions among children undergoing intensive diabetes management. Therefore, the majority of intensive diabetes therapy studies in children did not meet the inclusion criteria for this review. All three studies that met our inclusion criteria^21,^,^34,39^ reported improved metabolic control after initiation of the intensive treatment which persisted up to 1 year later. Two of the studies compared refinements to the education provided as a component of intensive diabetes management.^21,39^ The results of both studies suggest that educational interventions may support the effects of intensive diabetes management in reducing HbA1c.

All three studies reported on frequency of DKA and hypoglycemia. Grey et al.^21^ found that the overall rate of severe hypoglycemia was higher than the rate reported in the adolescent cohort of the DCCT of 88/100 patient-years. In the cohort study by Lawson et al.^39^ there were two severe hypoglycemic reactions in the individualized education group. In the camp study,^34^ intensive diabetes management had no effect on the frequency of mild to moderate hypoglycemia, and there were no severe episodes of hypoglycemia. Among the three studies, there was only one episode of DKA. Therefore, in terms of short-term acute complications, the studies show mixed results with one study reporting an unacceptably high level of severe hypoglycemia suggesting that further educational interventions need to be explored.

### b. A decrease in or prevention of diabetes-related complications (as measured by retinal, renal, cardiovascular and neurological evaluations), as demonstrated by DCCT?

No evidence was available to answer this question as none of the studies reported on long-term diabetes complications and all followed patients for less than 2 years. Although the Lawson study included patients who had nephromegaly, the progression of this complication was not monitored and patients were followed for only 15 months.^39^

## Limitations

Several limitations of this review need to be discussed. They are associated with weak study designs, potential for publication bias, and heterogeneity in interventions, outcome measurements, and control group definitions.

Although the majority of included studies were RCTs or CCTs, all but four RCTs received a low methodological score of 1 or 2 of a possible 5 points. These studies were considered weak in quality, mainly due to educational interventions not lending themselves to double blinding. Although there has been some debate as to whether this is a serious flaw in studies that examine behavioral outcomes,^121,122^ it still indicates that there is a potential for performance bias in outcome assessment. In the majority of the RCTs, the method by which the randomization code was derived, concealed, and allocated was also not reported, thereby leaving the studies open to the question of selection bias. Additionally, 25 percent of included studies were uncontrolled-before-and-after studies, which are not considered a rigorous a design as it is difficult to determine whether any effects are solely accounted for by the intervention.

Potential for publication bias is an issue relevant to all systematic reviews. To minimize publication bias, an experienced research librarian conducted a comprehensive search of the published literature for potentially relevant studies using a systematic strategy. We also searched conference proceedings, theses and dissertations, and grey literature, including professional websites in order to obtain additional relevant studies. In addition, we handsearched reference lists of reviews and included studies. We restricted the search to English language articles because we felt the majority of relevant research would be published in English language reports. Selection bias was minimized via the use of a priori inclusion criteria which were applied by two reviewers independently. Any discrepancies were resolved with a third party who had clinical expertise in diabetes management.

A particular limitation of this review was the variety of interventions and outcome measures across studies, which meant that we were not able to pool results. Although we combined interventions under broad categories, there was still significant heterogeneity within these categories. Moreover, some interventions were targeted to the child, the parent, or the family or peers, and some interventions were single component while others were multifaceted. Likewise, there were a wide variety of endpoints and outcome measurement instruments. Similarly, control groups were not defined the same way in all studies; some studies specified no intervention, while others specified standard care, which may not be consistent across different regions. Due to lack of time and resources, we did not contact authors directly to determine the breakdown of components in control groups.

## Conclusions

Overall, the studies included in this review did not show consistent and coherent effects over the examined outcomes. Therefore, we have limited confidence in our ability to identify one particular intervention above another to improve diabetes control, reduce short-term acute complications, or improve quality of life.

Although we had a number of higher quality trials, disparate interventions, populations, and outcomes made it difficult to determine whether one form of diabetes education was more effective than another. Furthermore, because most control groups also received some level of education, the studies may not have had sufficient power to detect a clinically or statistically significant difference in the various outcomes examined. It is also important to remember that trials often take place in tertiary settings where the patient population may be better educated, and where established educational programs may exist; the studies may not have had power to find differences between study groups. Further testing using strong study designs (e.g., cluster RCTs), clearly defined study populations and interventions, and standard and validated measurement instruments may help to elucidate this.

## Future Research Opportunities

To date, research in diabetes education is characterized by a great deal of heterogeneity and few long-term studies.

- Data from this review suggest there is a need for appropriately powered RCTs assessing cognitive behavioral therapy, family systems therapy, motivational interviewing, and frequency of contact with health care professionals on HbA1c and short-term complications, particularly in a population with poorly controlled diabetes.
- Future RCTs should specify the components of their “standard care” education and followup. A survey of standard education programs for diabetes so that researchers are aware of the diversity of standard care would be a useful addition to the literature.
- Nutrition therapy is a significant component of diabetes management. This review documents that very few studies have assessed specifically this component of diabetes education, and even fewer have assessed its effect on metabolic control. Additional research is needed in this area. For example, different educational formats for providing nutritional information may be more effective in improving knowledge, practice and metabolic control than others.
- The effect of interventions on quality of life was difficult to assess in this review because of the small number of studies that assessed this outcome and the use of a multitude of outcome tools. Future studies should include quality of life as an outcome measure and researchers in this area should work toward adopting a common validated instrument.
- Since diabetes-related complications develop over many years, longer term cohort studies and trials with longer followup will be essential to assess the effect of education on long-term complications of diabetes.
- Well-designed studies that address the challenges of conducting research on behavioral interventions are needed. Strong study designs such as cluster randomized trials should be used and steps should be taken to minimize the risks of bias. Although blinding may be difficult to achieve with educational and behavioral interventions, it should be possible to perform RCTs with the practice of using blinded outcome assessors. Concealment of allocation is always possible and should be reported.
- The DCCT and several subsequent reports have shown the benefit of intensive diabetes management on HbA1c in children and adolescents. Studies are needed to examine the aspects of education that improve outcomes with this management approach. Followup of the previous DCCT cohort (EDIC study) has found that the HbA1c rises over time. Studies are needed to explore education interventions that might lessen this deterioration in control.