# 3 Results

## Literature Search

The combined search strategies identified 12,740 citations from electronic databases and 17 references identified by gray literature and hand searching. Through screening titles and abstracts, 473 references were identified for further examination. The manuscripts of 46 articles could not be retrieved (Appendix D). The majority of these studies were abstracts from conference proceedings and dissertations. They were requested through the university interlibrary loan service, but did not arrive within the 7-month cutoff that we established for article retrieval. Therefore, the full text of 427 potentially relevant articles was retrieved and evaluated for inclusion in the review. The application of the selection criteria to the 427 articles resulted in 100 articles being included and 327 excluded. Figure 2 outlines study retrieval and selection for the review.

Figure 2. Flow-diagram for study retrieval and selection

From 100 included articles, 14 ^5,^ ^6,^ ^9,^ ^21,^ ^24,^ ^28,^ ^30,^ ^38,^ ^52,^ ^66,^ ^70,^ ^79,^ ^82,^ ^83^ were associated with multiple publications that either expanded on the main results of the primary study or reported secondary outcomes not included in the main report. The secondary publications were not considered as unique studies and any information they provided was included with the data reported in the primary study. In most instances, the report that provided data for the longest followup period was regarded as the primary study; otherwise, the study that was published first was considered the main one. Appendix E identifies the associated secondary publications for each primary study. In total, 80 primary studies were included in this report. ^5^ – ^84^

The four main reasons for excluding studies from this review were (1) the population did not include children (≤ 18 years) with type 1 diabetes or their families (n = 108), (2) the study was not primary research on diabetes education (e.g., systematic reviews, descriptive studies) (n = 93), (3) the study did not address diabetes education (n = 50), and (4) the study did not include a description of the intervention in sufficient detail to replicate it or report measurable data for outcomes relevant to the review (n = 37). Thirty-eight studies were excluded for other reasons including small sample size (n = 9). The list of excluded studies and reasons for exclusion are identified in Appendix D.

## Description of Included Studies

Eighty primary studies provided evidence regarding the effectiveness of diabetes education for children with type 1 diabetes and their families. Tables F1 and F2 (Appendix F) summarize the key characteristics of studies included in the review. Studies were published between 1983 and 2007 (median = 1996 [IQR, 1990 to 2001]). Most of the studies (88 percent) were published as peer reviewed publications; the remainder were theses or dissertations. Studies were conducted in the United States (64 percent), Europe (21 percent), Canada (9 percent), and other regions (6 percent).

Of the 80 included studies, 42 (53 percent) were RCTs. All were parallel trials. Eight of the trials had three arms ^5,^ ^13,^ ^17,^ ^32,^ ^52,^ ^63,^ ^82,^ ^83^ and one had four arms. ^24^ Eleven (14 percent) of the included studies were CCTs, ^7,^ ^14,^ ^19,^ ^42,^ ^45,^ ^48,^ ^51,^ ^62,^ ^74,^ ^76,^ ^84^ and 20 (25.0 percent) were uncontrolled before-after studies. ^11,^ ^12,^ ^20,^ ^27,^ ^28,^ ^34,^ ^35,^ ^37,^ ^44,^ ^50,^ ^53,^ ^61,^ ^64,^ ^65,^ ^67,^ ^68,^ ^73,^ ^75,^ ^77,^ ^78^ There were seven (9 percent) cohort studies: three prospective cohorts with concurrent controls, ^29,^ ^66,^ ^69^ two prospective cohorts with historical controls, ^40,^ ^54^ and two retrospective cohorts. ^39,^ ^41^

The number of enrolled participants in the studies ranged from 11 to 332 (median = 50 [IQR, 30 to 89]). The mean age of study participants ranged from 2.7 to 16 years. For 28 studies (35 percent), the mean age of participants was less than 12 years. ^11,^ ^17^ – ^19,^ ^22,^ ^24,^ ^26,^ ^30,^ ^32,^ ^35,^ ^36,^ ^38,^ ^40^ – ^44,^ ^47,^ ^49,^ ^50,^ ^55,^ ^66,^ ^70,^ ^71,^ ^77,^ ^78,^ ^80,^ ^84^ Ten ^17^ – ^19,^ ^26,^ ^30,^ ^40,^ ^49,^ ^66,^ ^69,^ ^70^ studies (13 percent) examined education interventions delivered to children and their families at the time of diagnosis with type 1 diabetes. Fourteen studies ^8,^ ^13^ – ^16,^ ^25,^ ^28,^ ^34,^ ^43,^ ^51,^ ^55,^ ^57,^ ^76,^ ^83^ (18 percent) examined interventions targeted at children who demonstrated poor metabolic control, which was defined as children with HbA1c above a certain level, as well as, in some studies, problems with adherence control. Although the populations of several other studies had mean HbA1c levels equivalent to or higher than those exhibited by children in studies targeted for poor metabolic control (i.e., greater than 9.0 percent), ^5,^ ^7,^ ^10^ – ^12,^ ^21,^ ^24,^ ^25,^ ^31^ – ^33,^ ^36,^ ^39,^ ^46,^ ^47,^ ^56,^ ^63,^ ^72,^ ^79,^ ^80,^ ^82,^ ^84^ the samples in these studies were not specifically selected on this basis and, therefore, were not included in this grouping.

The interventions examined were diverse. We grouped the interventions into nine broad categories. General diabetes education was assessed in 21 studies (26 percent). ^9,^ ^15,^ ^18,^ ^24,^ ^30,^ ^32,^ ^39,^ ^41,^ ^42,^ ^44,^ ^50,^ ^55,^ ^61,^ ^65,^ ^66,^ ^69,^ ^71,^ ^73,^ ^75,^ ^77,^ ^79^ Cognitive behavioral therapy and its variants was evaluated in 24 studies (30 percent). ^6^ – ^8,^ ^13,^ ^14,^ ^16,^ ^17,^ ^19^ – ^23^ ^25,^ ^31,^ ^33,^ ^45,^ ^47,^ ^48,^ ^54,^ ^72,^ ^74,^ ^76,^ ^80^ Family therapy interventions were considered in nine studies (11 percent). ^5,^ ^26,^ ^28,^ ^36,^ ^38,^ ^63,^ ^70,^ ^82,^ ^83^ Skills training programs were the focus of seven studies (8.8 percent). ^11,^ ^40,^ ^43,^ ^49,^ ^52,^ ^53,^ ^57^ Programs that were delivered as part of a diabetes camp were assessed in 17 studies (21 percent). ^12,^ ^29,^ ^60,^ ^67,^ ^78^ ^27,^ ^34,^ ^35,^ ^37,^ ^46,^ ^58,^ ^59,^ ^62,^ ^64,^ ^68,^ ^81,^ ^84^ The remaining interventions included psychotherapy ^51,^ ^56^ and a physical activity program (3 percent). ^10^

Only 20 of the included studies (25 percent) explicitly described the theoretical framework upon which they were based (e.g., anchored instruction, social cognitive theory). ^9,^ ^17,^ ^22,^ ^26,^ ^28^ – ^30,^ ^33,^ ^46,^ ^51,^ ^58^ – ^60,^ ^62,^ ^64,^ ^70,^ ^77,^ ^80,^ ^83,^ ^84^

More than half of the interventions (n = 43; 54 percent) were targeted at both children and parents or the family. Thirty-two education programs were delivered directly to the child. ^7^ – ^10,^ ^12^ – ^14,^ ^21,^ ^23,^ ^25,^ ^27,^ ^31,^ ^33^ – ^35,^ ^37,^ ^42,^ ^45,^ ^46,^ ^50,^ ^57^ – ^60,^ ^62,^ ^64,^ ^66^ – ^68,^ ^81,^ ^84^ Parents were the target audience in four studies (5 percent). ^19,^ ^30,^ ^36,^ ^44^ In one study, ^20^ the intervention focused on the child and a close friend; in another, the intervention was aimed at the child, family, and school staff. ^54^

The education interventions were delivered in a variety of settings. Most took place in a health care setting, such as a diabetes center (n = 12, 15 percent), outpatient clinic (n = 9, 11 percent), hospital (n = 10, 13 percent) or a combination of health care setting and other location (n = 15, 19 percent). A diabetes camp was the setting for 17 studies (21 percent). The education program was delivered at home in six studies (8 percent) and at summer school in one study. In 11 studies (14 percent), the setting in which the intervention took place was either not reported or unclear.

The duration of the education intervention ranged from 1 day to 2 years. For 28 studies (35 percent), the interventions were delivered for less than 1 month. For 10 studies (13 percent) the education program took place over 1 year or longer. ^5,^ ^6,^ ^11,^ ^17,^ ^18,^ ^21,^ ^38,^ ^54,^ ^71,^ ^79^ The duration of the intervention was not reported in six studies (8 percent).

Followup assessments were defined as those taken at time points after the immediate post-intervention assessment. In 21 studies (26 percent), ^6,^ ^9^ – ^12,^ ^20,^ ^21,^ ^24,^ ^27,^ ^31,^ ^32,^ ^38,^ ^41,^ ^50,^ ^57,^ ^60,^ ^64,^ ^73,^ ^79,^ ^81,^ ^118^ there were no outcome measurements taken after the post-intervention assessment, including studies in which outcomes were measured throughout the delivery of the education program. In 55 studies that identified specific followup periods, the periods ranged from 2 days to more than 4 years (median = 6 months [IQR, 3 to 12 months]). In two ^19,^ ^42^ studies (3 percent), the followup periods were not consistent among participants and were reported in ranges (i.e., 4 to 22 weeks and 6 to 24 months). In one ^54^ study, the followup was reported as 248 patient-years with 122 participants completing the study. The followup period was not reported in two ^45,^ ^68^ studies (3 percent). The followup period was less than 3 months in five ^23,^ ^25,^ ^26,^ ^58^ studies (6 percent). Followup assessments took place between 3 and 5 months in 18 studies (23 percent) ^7,^ ^8,^ ^13,^ ^15,^ ^16,^ ^29,^ ^33,^ ^36,^ ^37,^ ^44,^ ^46,^ ^47,^ ^62,^ ^67,^ ^72,^ ^78,^ ^80,^ ^84^ and between 6 and 11 months in 10 studies (13 percent). ^22,^ ^28,^ ^30,^ ^56,^ ^59,^ ^61,^ ^63,^ ^65,^ ^77,^ ^83^ For the remaining 21 studies (26 percent), the followup assessments were measured at 12 months or more.

## Methodological Quality of Included Studies

### Randomized Controlled Trials

Overall, the methodological quality of the 42 RCTs was low (median Jadad ^101^ score = 2/5; IQR, 1 to 2). The Jadad score was 3 for 4 trials, ^30,^ ^55,^ ^57,^ ^83^ , 2 for 31 trials ^5,^ ^6,^ ^10,^ ^16^ – ^18,^ ^21,^ ^24^ – ^26,^ ^31^ – ^33,^ ^36,^ ^38,^ ^43,^ ^46,^ ^47,^ ^56,^ ^60,^ ^72,^ ^82^ ^13,^ ^15,^ ^22,^ ^23,^ ^58,^ ^59,^ ^70,^ ^71,^ ^81^ and 1 for 7 trials ^8,^ ^9,^ ^49,^ ^52,^ ^63,^ ^79,^ ^80^ (Table 3). All were described as randomized; however, the descriptions of randomization varied. Five were adequately randomized; ^30,^ ^32,^ ^55^ – ^57,^ ^83^ the rest were unclear. Two trials reported clear concealment of allocation ^30,^ ^83^ and the remaining trials were unclear. No trials were described as double-blind (patient and outcome assessor blinded). Withdrawals and dropouts were clearly described in 33 trials; in 9 studies, withdrawals and dropouts were not described. ^8,^ ^9,^ ^32,^ ^49,^ ^52,^ ^56,^ ^63,^ ^79,^ ^80^ The post hoc assessment of blinding revealed that 11 RCTs had included an attempt to blind outcome assessors. ^17,^ ^18,^ ^21,^ ^23,^ ^26,^ ^52,^ ^56,^ ^56,^ ^59,^ ^71,^ ^72,^ ^80^

Table 3 Methodological quality and source of funding of randomized controlled trials assessing the effectiveness of diabetes education for children with type 1 diabetes and their families

Author Year | Randomization | | Double Blinding | | Description of Withdrawals/Dropouts | Jadad Score (out of 5) | Allocation Concealment | Funding Source
Stated | Method Described | Stated | Method Described
Anderson ^6^ 1989 | Yes | No | No | No | Yes | 2 | Unclear | Government
Anderson ^5^ 1999 | Yes | No | No | No | Yes | 2 | Unclear | Government, foundation
Boardway ^8^ 1993 | Yes | No | No | No | No | 1 | Unclear | Government
Brown ^9^ 1997 | Yes | No | No | No | No | 1 | Unclear | Government, industry
Campaigne ^10^ 1985 | Yes | No | No | No | Yes | 2 | Unclear | Government
Cigrang ^13^ 1992 | Yes | No | No | No | Yes | 2 | Unclear | NR
Coupland ^15^ 1992 | Yes | No | No | No | Yes | 2 | Unclear | NR
Delamater ^17^ 1990 | Yes | No | No | No | Yes | 2 | Unclear | Government, internal
Delamater ^16^ 1991 | Yes | No | No | No | Yes | 2 | Unclear | Government, foundation
Dougherty ^18^ 1999 | Yes | No | No | No | Yes | 2 | Unclear | Government
Grey ^21^ 2000 | Yes | No | No | No | Yes | 2 | Unclear | Government, foundation, internal
Gross ^23^ 1983 | Yes | No | No | No | Yes | 2 | Unclear | Internal
Gross ^22^ 1985 | Yes | No | No | No | Yes | 2 | Unclear | Government
Hackett ^24^ 1989 | Yes | No | No | No | Yes | 2 | Unclear | Government
Hains ^25^ 2000 | Yes | No | No | No | Yes | 2 | Unclear | Industry
Hakimi ^26^ 1998 | Yes | No | No | No | Yes | 2 | Unclear | NR
Hoff ^30^ 2005 | Yes | Yes | No | No | Yes | 3 | Adequate | Private
Horan ^31^ 1990 | Yes | No | No | No | Yes | 2 | Unclear | Government
Howe ^32^ 2005 | Yes | Yes | No | No | No | 2 | Unclear | NR
Kaplan ^33^ 1985 | Yes | No | No | No | Yes | 2 | Unclear | Government, foundation
Kennedy-Iwai ^36^ 1991 | Yes | No | No | No | Yes | 2 | Unclear | NR
Laffel ^38^ 2003 | Yes | No | No | No | Yes | 2 | Unclear | Government, foundation, private
Mann ^43^ 1984 | Yes | No | No | No | Yes | 2 | Unclear | Industry
Massouh ^46^ 1989 | Yes | No | No | No | Yes | 2 | Unclear | Hospital
McNabb ^47^ 1994 | Yes | No | No | No | Yes | 2 | Unclear | Government
Mitchell ^49^ 1996 | Yes | No | No | No | No | 1 | Unclear | NR
Nordfeldt ^52^ 2005 | Yes | No | No | No | No | 1 | Unclear | Foundation, government, internal
Nunn ^55^ 2006 | Yes | Yes | No | No | Yes | 3 | Unclear | Internal
Olmsted ^56^ 2002 | Yes | Yes | No | No | No | 2 | Unclear | Government
Panagiotopoulos ^57^ 2003 | Yes | Yes | No | No | Yes | 3 | Unclear | Foundation
Pichert ^60^ 1993 | Yes | No | No | No | Yes | 2 | Unclear | NR
Pichert ^58^ 1994a | Yes | No | No | No | Yes | 2 | Unclear | Government
Pichert ^59^ 1994b | Yes | No | No | No | Yes | 2 | Unclear | Government
Satin ^63^ 1989 | Yes | No | No | No | No | 1 | Unclear | Government
Sundelin ^70^ 1996 | Yes | No | No | No | Yes | 2 | Unclear | Foundation
Svoren ^71^ 2003 | Yes | No | No | No | Yes | 2 | Unclear | Government, foundation, private
Szumowski ^72^ 1990 | Yes | No | No | No | Yes | 2 | Unclear | Foundation
Wadham ^79^ 2005 | Yes | No | No | No | No | 1 | Unclear | NR
Webb ^80^ 1999 | Yes | No | No | No | No | 1 | Unclear | NR
Wolanski ^81^ 1996 | Yes | No | No | No | Yes | 2 | Unclear | NR
Wysocki ^83^ 2000 | Yes | Yes | No | No | Yes | 3 | Adequate | Government
Wysocki ^82^ 2007 | Yes | No | No | No | Yes | 2 | Unclear | Government

NR = not reported

The most common source of funding was government (n = 24, 57 percent of RCTs). Three trials (7 percent) received funding from industry. ^9,^ ^25,^ ^43^ Other sources of funding included foundations (n = 10, 24 percent), internal (n = 7, 17 percent), and private (n = 4, 10 percent). For nine trials (21 percent), the funding is not known. ^13,^ ^15,^ ^26,^ ^32,^ ^36,^ ^49,^ ^79^ – ^81^ Several trials received funding from multiple sources (Table 3). ^5,^ ^9,^ ^16,^ ^17,^ ^21,^ ^33,^ ^38,^ ^52,^ ^71^

### Controlled Clinical Trials

The methodological quality of the 11 CCTs was low (median modified Jadad ^101^ score = 1/3; IQR, 0 to 1) (Table 4). Seven CCTs (64 percent) obtained only 1 point for the individual components of the Jadad scale, all for the description of withdrawals and dropouts. The remaining four trials did not score any points. ^42,^ ^45,^ ^51,^ ^84^

Table 4 Methodological quality and source of funding for controlled clinical trials assessing the effectiveness of diabetes education for children with type 1 diabetes and their families

Author Year | Randomization | | Double Blinding | | Description of Withdrawals/Dropouts | Jadad Score (out of 3) | Allocation Concealment | Funding Source
Stated | Method Described | Stated | Method Described
Barglow ^7^ 1983 | NA | NA | No | No | Yes | 1 | NA | NR
Couper ^14^ 1999 | NA | NA | No | No | Yes | 1 | NA | Government
Golden ^19^ 1985 | NA | NA | No | No | Yes | 1 | NA | Internal
Lucey ^42^ 1985 | NA | NA | No | No | No | 0 | NA | NR
Mason ^45^ 1985 | NA | NA | No | No | No | 0 | NA | NR
Mendez ^48^ 1997 | NA | NA | No | No | Yes | 1 | NA | NR
Moran ^51^ 1991 | NA | NA | No | No | No | 0 | NA | Foundation, private, internal
Remley ^62^ 1999 | NA | NA | No | No | Yes | 1 | NA | NR
Thomas-Dobersen ^74^ 1993 | NA | NA | No | No | Yes | 1 | NA | Government
Viner ^76^ 2003 | NA | NA | No | No | Yes | 1 | NA | Private
Zorumski ^84^ 1997 | NA | NA | No | No | No | 0 | NA | NR

NA = not applicable; NR = not reported

The CCTs received funding from government sources (n = 2), foundations (n = 2), internal (n = 2), and private sources (n = 2) (Table 4). One trial received funding from multiple sources. ^51^ For six studies (55 percent), the funding source is not known. ^7,^ ^42,^ ^45,^ ^48,^ ^62,^ ^84^

### Before and After Studies

The quality of reporting of the 20 before-and-after studies was evaluated using individual components of the Thomas tool. ^105^ Overall, the methodological quality of the before-and-after studies was weak (Table 5 and Table F3, Appendix F). For 10 (50 percent) studies participants were unlikely to be representative of the target population and were rated as weak on the selection bias component. The remaining studies were rated as moderate. Control of potential confounders (age, sex, duration of diabetes, socioeconomic status) was rated as weak for 13 (65 percent) studies. None of the studies reported the blinding of outcome assessors to the intervention. Data collection methods were rated as strong for 12 (60 percent) studies. For the remaining eight, the reliability and validity of the data collection tools was not reported. The risk of attrition bias was moderate with 14 (70 percent) studies rated as strong or moderate on this component. Data analysis was appropriate in most studies. None of the studies provided a sample size calculation. Nine studies reported a statistically significant difference between groups for the primary outcome, five studies found no significant differences, and six studies did not report whether group differences were statistically significant. Overall, the intervention integrity was moderate. For 19 (95 percent) studies, over 80 percent of participants received the allocated intervention. Methods to assess the consistency of the intervention were included in eight (40 percent) studies; for the remainder they were not reported. For most studies (n = 14, 70 percent), it was unlikely that contamination occurred or that there was a cointervention. For the remaining six, there was insufficient information to answer this question. Finally, funding source was disclosed in 70 percent (n = 14) of the before-and-after studies (Table 5).

Table 5 Methodological quality of before-and-after studies and cohort studies

Author Year | Selection Bias | Study Design | Confounders | Blinding | Data Collection Methods | Withdrawals/Dropouts | Funding Source
Uncontrolled before-and-after studies
Caravalho ^11^ 2000 | Weak | Weak | Moderate | Weak | Strong | Moderate | NR
Christensen ^12^ 2000 | Weak | Weak | Weak | Weak | Weak | Strong | Government, internal
Greco ^20^ 2001 | Moderate | Weak | Moderate | Weak | Strong | Strong | Foundation
Harkavy ^27^ 1983 | Moderate | Weak | Moderate | Weak | Weak | Strong | Government
Harris ^28^ 2005 | Weak | Weak | Weak | Weak | Strong | Strong | Internal
Karaguzel ^34^ 2005 | Weak | Weak | Weak | Weak | Weak | Strong | Internal
Kemp ^35^ 1986 | Weak | Weak | Weak | Weak | Strong | Weak | Industry
Koontz ^37^ 2002 | Moderate | Weak | Strong | Weak | Strong | Weak | NR
Marteau ^44^ 1987 | Weak | Weak | Weak | Weak | Weak | Strong | NR
Monaco ^50^ 1996 | Moderate | Weak | Weak | Weak | Strong | Strong | NR
Povlsen ^61^ 2005 | Weak | Weak | Weak | Weak | Weak | Moderate | Government, foundation, private
Schlundt ^64^ 1996 | Weak | Weak | Weak | Weak | Strong | Weak | Government
Shobhana ^65^ 1997 | Moderate | Weak | Weak | Weak | Weak | Weak | Industry
Smith ^68^ 1991 | Moderate | Weak | Weak | Weak | Weak | Strong | NR
Smith ^67^ 1993 | Moderate | Weak | Moderate | Weak | Strong | Weak | NR
Templeton ^73^ 1988 | Weak | Weak | Weak | Weak | Weak | Strong | Government
Verrotti ^75^ 1993 | Weak | Weak | Moderate | Weak | Strong | Strong | NR
von Sengbusch ^77^ 2006 | Moderate | Weak | Moderate | Weak | Strong | Strong | Other
Vyas ^78^ 1988 | Moderate | Weak | Weak | Weak | Strong | Moderate | NR
Cohort studies
Hill ^29^ 2006 | Weak | Weak | Weak | Weak | Strong | Weak | Professional association
Lawson ^39^ 2000 | Weak | Weak | Weak | Weak | Strong | Strong | Foundation
Likitmaskul ^40^ 2002 | Moderate | Weak | Weak | Weak | Strong | Strong | Private
Lipman ^41^ 1988 | Moderate | Weak | Weak | Weak | Strong | Strong | NR
Nordfeldt ^54^ 1999 | Strong | Weak | Weak | Weak | Weak | Strong | Foundation
Nordfeldt ^53^ 2002 | Moderate | Weak | Weak | Weak | Strong | Weak | Foundation, government, internal
Siminerio ^66^ 1999 | Moderate | Weak | Moderate | Weak | Strong | Strong | Internal
Srinivasan ^69^ 2004 | Moderate | Weak | Weak | Weak | Strong | Strong | NR

NR = not reported

### Cohort Studies

The quality of reporting of the seven cohort studies was evaluated with individual components of the Thomas tool. ^105^ (Table 5 and Table F3, Appendix F). Overall, the methodological quality was moderate. Most studies did a reasonable job of protecting against selection bias with five of seven (71 percent) choosing study groups that were at least somewhat representative of the target population. The risk of attrition bias was low; all but one study included a description of the number of withdrawals and the followup rates were unlikely to introduce differences between the comparison groups. Data collection methods were assessed as valid and reliable for six studies (86 percent). Control of potential confounders (age, sex, duration of diabetes, socioeconomic status) either in the design or analysis was rated as weak for six (86 percent) studies and as moderate in one study (14 percent). No studies reported that the ascertainment of outcome exposure was blinded. For all studies data analysis was considered appropriate. None of the studies provided a sample size calculation; however, four studies (57 percent) reported a statistically significant difference between groups for the primary outcome. Intervention integrity was good. In six studies (86 percent), over 80 percent of participants received the allocated intervention and the risk of contamination or cointervention was low. Finally, three of the cohort studies (43 percent) reported the source of funding (Table 5).

## Results of Included Studies

This section is organized by major outcome categories: HbA1c, health service utilization, complications, knowledge, skills, behavior, psychosocial outcomes, quality of life, and school performance. For each outcome category, we provide a brief overview of the studies that contributed data to the outcome and a qualitative summary of the results. Due to considerable heterogeneity across the studies in terms of specific outcome measures, intervention, study population, and study design, we were unable to pool the results of any of the studies.

## HbA1c

Overall, there were 52 studies that assessed the effectiveness of diabetes education in improving metabolic control as measured by HbA1c. Of these, 30 studies assessed the general population of children with type 1 diabetes, 8 studies focused on children with newly diagnosed diabetes, and 14 studied children with poorly controlled diabetes.

### General Diabetes Education—HbA1c

Description of studies. We identified 12 studies (7 RCTs, ^9,^ ^15,^ ^18,^ ^24,^ ^32,^ ^55,^ ^79^ 2 cohorts, ^39,^ ^69^ 3 uncontrolled before-and-after ^61,^ ^75,^ ^77^ ) that assessed the effectiveness of general diabetes education on HbA1c. Studies were conducted in the United States, ^9,^ ^32^ Europe, ^24,^ ^61,^ ^75,^ ^77,^ ^79^ Canada, ^15,^ ^18,^ ^39^ and Australia. ^55,^ ^69^ The median year of publication was 2003 (IQR, 1995 to 2005).

The number of participants enrolled in the studies ranged from 28 to 146 (median = 65 [IQR 35 to 109]). The mean age of participants ranged from 10 to 15.8 years (n = 9 studies). For 3 studies, the mean age was less than 12 years. ^18,^ ^55,^ ^77^ Two studies examined education interventions delivered to children and their families at the time of diagnosis. ^18,^ ^69^ Two studies focused on children who demonstrated poor metabolic control. ^15,^ ^55^

Most interventions were targeted to children and their parents or to the entire family; ^9,^ ^15,^ ^18,^ ^32,^ ^39,^ ^55,^ ^61,^ ^69,^ ^75,^ ^77,^ ^79^ one was delivered to the child. ^24^ The settings for the interventions were described as a hospital inpatient unit, ^61,^ ^77^ outpatient clinic, ^24,^ ^79^ or home. ^9^ For 5 studies, the setting was mixed (e.g., diabetes center and home). ^18,^ ^32,^ ^39,^ ^55,^ ^69^ The setting was not clearly described in 2 studies. ^15,^ ^75^

Five studies did not measure HbA1c beyond the completion of the education program. ^9,^ ^24,^ ^32,^ ^55,^ ^79^ In the 7 studies that reported post-intervention assessments, ^15,^ ^18,^ ^39,^ ^61,^ ^69,^ ^75,^ ^77^ the median followup period was 12 months and ranged from 3.5 to 36 months.

### Results

General population of children with diabetes. Howe et al. ^32^ randomly assigned 75 patients to one of three treatment groups: standard care (routine quarterly clinic visits), standard care plus one education session on basic diabetes management skills, and standard care plus the education session plus weekly telephone calls to review management techniques. At 6 months, mean HbA1c levels dropped slightly from baseline (0.3 percent, 0.4 percent, and 0.5 percent, respectively). The differences were not statistically significant; however, they do represent a clinical improvement for the education plus telephone call group. The trial was ended early due to lack of enrolment. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

The retrospective cohort study (n = 28) by Lawson et al. ^39^ compared intensive, individualized education to group education delivered to patients. The content for both interventions was the same. Both groups showed a statistically significant decrease in mean HbA1c at 3 months; however, over the next 12 months the HbA1c levels increased for both groups. For the individualized education cohort, the mean HbA1c remained significantly lower than at initiation of the program (9.5±0.3 vs. 8.2±0.4 percent, p = 0.001); for the group education cohort, the mean HbA1c was not significantly different than baseline (8.2±0.4 vs. 8.1±0.3 percent). However, the baseline levels for the group education cohort were significantly lower than for the individual education group (p = 0.02). The methodological quality of this study was rated as weak using the Thomas instrument.

Povlsen et al. ^61^ assessed the effect of an intervention targeted at 37 families from ethnic minority groups in Denmark. The intervention included adapted educational material and guidelines and re-education that focused on increasing knowledge and self-care. The authors reported a significant difference in mean HbA1c levels immediately after the 12-month intervention (9.2±1.4 vs. 8.6±1.0 percent, p = 0.01); however, this improvement disappeared at the 6-month followup. The methodological quality of this study was rated as weak using the Thomas instrument.

In an uncontrolled before-and-after study, von Sengbusch et al. ^77^ assessed the impact of a mobile diabetes education service in a group of 107 children. Overall HbA1c levels for the whole cohort did not change significantly. The researchers conducted a post hoc subgroup analysis and found that among children with poor metabolic control (defined as HbA1c >8.0 percent), there was improved metabolic control from baseline to 6-month followup (9.4±0.9 vs. 8.6±1.5 percent, p<0.01). The methodological quality of this study was rated as moderate using the Thomas instrument.

Brown et al. ^9^ randomly assigned 59 children and adolescents to a group that played a video game featuring characters with diabetes who manage their diabetes by monitoring blood glucose, taking insulin injections, and choosing foods, or a group that played a pinball video game with no information on diabetes. At the end of the 6-month study period, both groups exhibited higher levels of HbA1c (i.e., poorer metabolic control). There was no statistically significant difference between groups. The methodological quality of this study was rated as low (1/5 on the Jadad score; unclear allocation concealment).

In the RCT by Hackett et al., ^24^ three cohorts of families received educational packages that were delivered over 8 months. The content was the same for all groups and included a nutrition therapy education component; one group (cohort 1) received a second reinforcement package for an additional 8 months. The comparison group did not receive the education package. Overall, the education program did not have an impact on HbA1c levels. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Wadham et al. ^79^ conducted an RCT (n = 67) to evaluate a 4-session family centered, structured education program for adolescents and parents. The program focused on skill-based sessions and teamwork and communication between parents and adolescents. The control group received routine clinical care. Preliminary results at 6 months did not show any significant change in HbA1c levels for either group. The methodological quality of this study was rated as low (1/5 on the Jadad score; unclear allocation concealment).

In an uncontrolled before-and-after study Verrotti et al. ^75^ studied 30 adolescents who attended nine education sessions on general diabetes management. At the 12-month followup, mean baseline levels of HbA1c had decreased significantly (11.8±2.8 vs. 10.0±2.7 percent, p = 0.019). The methodological quality of this study was rated as moderate using the Thomas instrument.

Children with newly diagnosed diabetes. Dougherty et al. ^18^ randomly assigned 63 newly diagnosed patients to a 24-month home-based diabetes education program or to traditional hospitalization and outpatient followup. Treatment differences between the groups consisted of duration of initial hospital stay, timing of initial teaching, and the nature and extent of subsequent nursing followup. Both groups exhibited significantly lower mean HbA1c values at the 3-month followup. These differences were still present at 36 months, 1 year after the intervention ended (10.5±1.3 vs. 6.4±1.4 percent for the home-based group and 10.0±1.3 vs. 7.1±1.3 percent for the hospital-based group). The difference between the two groups at 36 months was statistically significant. The methodological quality of this study was rated as moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

In the prospective cohort study by Srivivasan et al. ^69^ a group of 61 newly diagnosed patients attended a diabetes day care program (DDCP) at which they received “survival skills” diabetes education. The pre-DDCP cohort comprised 49 patients who were admitted to hospital for 4 to 7 days for a detailed education program. Neither group demonstrated improvement in HbA1c levels at 3, 6 or 12-month followup. The methodological quality of this study was rated as moderate using the Thomas instrument.

Children with poorly controlled diabetes. Nunn et al. ^55^ randomly assigned 123 patients to receive scheduled telephone calls from a pediatric diabetes educator or standard care (i.e., routine clinic visits but no telephone calls). Over the course of the 8-month study HbA1c levels increased in both groups (i.e., poorer metabolic control). There was no statistically significant difference between groups. The methodological quality of this study was rated as high (3/5 on the Jadad score; unclear allocation concealment).

In the RCT by Coupland ^15^ adolescents and their families participated in a family-based intervention to improve adherence (n = 15); the comparison group (n = 14) comprised adolescents who were taught stress management techniques. At 6-month followup, both the intervention and comparison groups demonstrated significant improvements in mean HbA1c (11.6±1.41 vs. 9.8±2.23 percent and 11.3±1.22 to 10.5±1.57 percent, respectively). There was no statistically significant difference between groups. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

### Cognitive Behavioral Therapy—HbA1c

Description of studies. Nineteen studies (14 RCTs, ^5,^ ^6,^ ^8,^ ^13,^ ^16,^ ^17,^ ^21,^ ^22,^ ^25,^ ^31,^ ^33,^ ^47,^ ^72,^ ^80^ 4 CCTs, ^7,^ ^14,^ ^19,^ ^76^ 1 cohort ^54^ ) examined various interventions that used cognitive behavioral therapy techniques. All but three studies were conducted in the United States; two were conducted in Europe, ^54,^ ^76^ and one was conducted in Australia. ^14^ The median year of publication was 1992 (IQR, 1989 to 1999) and ranged from 1983 to 2003.

The number of participants enrolled in the studies ranged from 13 to 139 (median = 31 [IQR 20 to 69]). The mean age of participants ranged from 2.7 to 15.4 years (14 studies). For five studies, the mean age was less than 12 years. ^17,^ ^19,^ ^22,^ ^47,^ ^72^ Two studies examined education interventions delivered to children and their families at the time of diagnosis. ^17,^ ^19^ Six studies focused on children who demonstrated poor metabolic control. ^8,^ ^13,^ ^14,^ ^16,^ ^25,^ ^76^

In seven studies the interventions were delivered to children; ^7,^ ^8,^ ^13,^ ^14,^ ^21,^ ^25,^ ^31^ in two studies they were delivered to parents. ^19,^ ^33^ In the remaining studies parents and children or the entire family were targeted. ^5,^ ^6,^ ^16,^ ^17,^ ^22,^ ^47,^ ^54,^ ^72,^ ^76,^ ^80^ The settings for the interventions were described as a diabetes center, ^5,^ ^7,^ ^47^ hospital inpatient unit, ^6,^ ^13,^ ^25^ outpatient clinic, ^8,^ ^16,^ ^72,^ ^80^ home, ^31^ or summer school. ^33^ In four studies, the setting was mixed (e.g., diabetes center and home). ^14,^ ^17,^ ^21,^ ^54^ Two studies did not report the setting of the intervention. ^22,^ ^76^ All but three studies ^6,^ ^19,^ ^31^ conducted post-intervention assessments for HbA1c. The median followup period was 4 months and ranged from 1 month to 14 months.

### Results

General population of children with diabetes. Anderson et al. ^6^ randomized 70 adolescents and parents to a group that received standard care (routine clinic visits) or a group that received standard care plus a problem solving intervention that focused on self-monitoring of blood glucose (SMBG) around meal planning. At completion of the 18-month program, the intervention group exhibited a mean decrease of 0.37 percent in HbA1c levels compared with a mean increase of 0.62 percent in the standard care group. This difference was statistically significant (p = 0.04). The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

In a subsequent study, Anderson et al. ^5^ assessed the effectiveness of an intervention for families that focused on teamwork and shared parent-teen responsibility for diabetes tasks. Eighty-nine families were randomly assigned to the intervention group or to one of two comparison groups: standard care (routine clinical care from the diabetes team) or standard care plus didactic diabetes education. At the end of the 12-month program, there was no significant difference in mean HbA1c among the three groups. While the intervention group demonstrated improvement in HbA1c levels at the 12-month followup, there was no significant difference in change scores between the groups (-0.20±1.1 percent for the teamwork group vs. 0.11±1.1 percent for the combined comparison groups). The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Grey et al. ^21^ randomly assigned 77 adolescents to receive intensive diabetes management (IDM) as described in the DCCT or IDM plus a behavioral program of coping skills training intervention. At the 12-month followup, both groups reported significant decreases in HbA1c levels. The change from baseline measures of HbA1c for the intervention group was greater than the control group and the difference was statistically significant (9.1±1.5 vs. 7.5±1.1 percent and 9.2±1.4 vs. 8.5±1.4 percent, respectively; p<0.001). The methodological quality of this study was rated as moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

In the study by Kaplan et al., ^33^ 21 patients were randomly assigned to a group that received social skills training or a group that received lectures on diabetes. At the 4-month followup, the social skills group reported improved HbA1c levels compared with the comparison group (12.6±2.4 vs. 11.72 percent [SD not reported] and 13.5±1.6 vs. 14.42 percent [SD not reported]; p<0.05). The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

In a prospective study with historical controls, Nordfeldt and Ludvigsson ^54^ examined the effect of multiple dose insulin therapy combined with problem-based training and psychosocial support. The prospective cohort comprised 248 children admitted to hospital in 1994 and 1995. The comparison group (156 patients admitted in 1980-81) received standard clinical care. The researchers reported that the annual mean levels of HbA1c were significantly lower in the cohorts that received intensive diabetes training compared with the historical cohort that did not receive the same level of education and support (6.9±1.3 percent [1994], 7.1±1.1 percent [1995] and 7.4±1.2 [1980-81]; p = 0.004). The methodological quality of this study was rated as weak using the Thomas instrument.

In the study by McNabb et al. ^47^ 24 children were randomly assigned to either a 6-week self-management education program or to receive standard care (routine clinic visits). At the 6-week followup, HbA1c levels had decreased from baseline in both groups; however, the difference was not statistically significant (10.5±2.9 vs. 9.6±1.8 percent and 12.9±3.8 vs. 12.5±3.4 percent, respectively). The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Barglow et al. ^7^ conducted a CCT (n = 42) to assess the effectiveness of a 4-month intensive multicomponent treatment and education program. The comparison group received standard care (routine clinic visits). At the 4-month followup both groups reported lower levels of HbA1c (change from baseline = -2.45±2.3 percent and -0.85±3.5 percent, respectively); however, the difference was not statistically significant. The methodological quality of this study was rated as low (1/3 on the modified Jadad score).

In the RCT by Gross et al. ^22^ 14 children and parents were randomly assigned to either behavior modification training or to a group that included discussion and role-playing. Both the intervention and comparison groups exhibited improvement in metabolic control at the 6-month followup (13.0 vs. 12.5 percent and 13.4 vs. 11.0 percent, respectively). There was no statistically significant difference between the groups at followup. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Szumowski ^72^ randomly assigned 27 young children to an 8-week behavioral intervention that included information on diabetes management plus instruction and practice in the application of behavioral principles and goal setting to reinforce children's regimen adherence, or to the comparison group that received information on diabetes management but no additional instruction. At the 3-month followup there were no statistically significant changes from baseline HbA1c levels for either group. The methodological quality of this study was rated as moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

Horan et al. ^31^ conducted an RCT (n = 20) that compared goal setting and problem solving using dynamic computer-assisted teaching modules vs. conventional education using an education booklet. At the end of the 15-week program, there were no significant changes in HbA1c levels in either group. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

In the RCT by Webb, ^80^ 45 families were assigned to a group that received intensive collaborative goal setting training or a group that used a goal setting worksheet with guidance from a therapist. At the 3-month followup neither group showed a significant change from baseline HbAc1 levels. The methodological quality of this study was rated as low (1/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

Children with newly diagnosed diabetes. In the CCT by Golden et al. ^19^ 11 families received an integrated diabetes education and psychosocial support program that was delivered in a motel-like setting. The comparison group (n = 8) received the same training 15 months after diagnosis. Overall, the children whose families received immediate education achieved lower levels of HbA1c at all time points during the study up to 24 months after diagnosis (p<0.05). Baseline levels of HbA1c were not reported; therefore, we could not assess whether there was a significant change from baseline for either group. The methodological quality of this study was rated as low (1/3 on the modified Jadad score).

Delamater et al. ^17^ conducted an RCT (n = 36) that assessed the impact of a family-based self-management training (SMT) program conducted over the 6 months following diagnosis of diabetes. The description of the intervention included a medical nutrition therapy education component. One comparison group received standard care (regular outpatient contact with the health care team); a second comparison group received standard care plus supportive counseling. HbA1c measures taken at 12 and 24 months after diagnosis showed that all three groups improved their metabolic control. The SMT group had significantly lower HbA1c levels than the standard care patients at both 1 and 2 years after diagnosis (10.4±3.1 vs. 8.2±1.5 percent and 12.3±2.5 vs. 9.8±2.4 percent, respectively at 2 years). The SMT group also had lower levels than the supportive care group, but this difference was not statistically significant (10.4±3.1 vs. 8.2±1.5 percent and 11.1±2.4 vs. 9.1±1.7 percent, respectively at 2 years). The methodological quality of this study was rated as moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

Children with poorly controlled diabetes. In a CCT by Viner et al., ^76^ a 6-week motivational and solution-focused therapy group program was delivered to 21 adolescents and their parents. The control group comprised 20 adolescents who did not receive any intervention. At the 12-month followup, the intervention group demonstrated statistically significant decreases in HbA1c levels compared with the control group (10.2±1.37 vs. 8.9±1.37 percent and 10.0±1.34 vs. 9.9±2.24 percent, respectively). The methodological quality of this study was rated as low (1/3 on the modified Jadad score).

In a three-arm RCT (n = 37), Cigrang ^13^ investigated the effects of a coping skills program delivered to adolescents with a history of poor metabolic control. There were two comparison groups: conventional diabetes education and standard care (routine clinic visits). At the 3-month followup, HbA1c levels decreased for all three groups. The change from baseline for each group was clinically significant (1.06±1.31 percent, 0.94±2.25 percent, 0.92±1.74 percent, respectively); however, there were no statistically significant differences among the three groups. It is likely that the study did not have sufficient power to detect a difference among the groups. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Couper et al. ^14^ evaluated the effects of monthly home visits by a nurse educator plus weekly telephone calls that focused on goal-setting. Thirty-seven adolescents received routine care plus the intervention; 32 received routine clinical care only. At the 6-month followup, the intervention group reported statistically significant lower mean levels of HbA1c compared with the comparison group (11.1±1.3 vs. 9.7±1.6 percent and 10.5±1.6 vs. 10.3±2.2 percent, respectively [p = 0.0001]). The difference between HbA1c levels at baseline and the 18-month assessment in the intervention group were clinically, but not statistically, significant (11.1±1.3 vs. 10.0±1.5 percent [0.06]^1190.06^). The methodological quality of this study was rated as low (1/3 on the modified Jadad score; unclear allocation concealment).

Delamater et al ^16^ randomized 13 adolescents to receive a 2-month family-based behavior therapy program or to standard outpatient care. The description of this intervention included details of a medical nutrition therapy component. There were no significant changes in HbA1c levels in either group at the 4-month followup (11.5±2.1 vs. 11.0±2.4 percent and 10.4±0.8 vs. 10.3±1.5 percent, respectively). The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

In the RCT (n = 19) by Boardway et al. ^8^ a 3-month stress management training program for adolescents was compared to standard outpatient care. The intervention was not effective in reducing HbA1c levels. For the intervention group HbA1c increased (i.e., poorer metabolic control) at the 6-month followup; there was no change in HbA1c levels for the control group (13.98±2.41 vs. 16.4±2.41 percent and 15.75±3.52 vs. 15.69±2.76 percent, respectively). The methodological quality of this study was rated as low (1/5 on the Jadad score; unclear allocation concealment).

Hains et al. ^25^ randomly assigned 15 adolescents to a cognitive behavioral stress training program or to a control group that did not receive any intervention. At 1-month followup there were no significant changes in HbA1c levels for either group. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

### Family Therapy—HbA1c

Description of studies. Seven studies (6 RCTs, ^36,^ ^38,^ ^63,^ ^70,^ ^82,^ ^83^ 1 uncontrolled before-and-after ^28^ ) assessed interventions that focused on family dynamics. Six studies were conducted in the United States; one took place in Europe. ^70^ The median year of publication was 2000 and ranged from 1996 to 2007.

The number of participants enrolled in the studies ranged from 18 to 119 (median = 38 [IQR 19 to 105]). The mean age of participants ranged from 6.0 to 14.6 years. In three studies, the mean age was less than 12 years. ^28,^ ^36,^ ^70^ Two studies examined education interventions delivered to children and their families at the time of diagnosis. ^36,^ ^70^ Two studies focused on children who demonstrated poor metabolic control. ^28,^ ^83^

The interventions were targeted at the entire family in six studies; in one study the intervention was delivered to the parents only. ^36^ The settings for the interventions were described as a diabetes center, ^82^ hospital inpatient unit, ^63^ the doctor's office, ^83^ or home. ^28,^ ^36^ For two studies, the setting was mixed (e.g., diabetes center and home). ^38,^ ^70^ Two studies reported HbA1c levels immediately following the intervention. ^38,^ ^83^ Four studies conducted post-intervention assessments for HbA1c. ^28,^ ^63,^ ^70,^ ^82^ The median followup period was 6 months and ranged from 3 to 24 months.

### Results

General population of children with diabetes. Wysocki et al. ^82^ randomized 104 families to one of three groups: standard care plus behavioral family systems therapy (BFST), standard care plus family education and support, or standard care (physician directed clinical care). At the completion of the 6-month intervention, all groups showed improvement in mean HbA1c levels. However, only the BFST group maintained their improved HbA1c levels at 12-month followup, while both comparison groups reverted toward their baseline levels (BFST group: 9.6±1.6 percent at baseline vs. 8.8±1.5 percent at 12 months). The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Satin et al. ^63^ randomly assigned 32 adolescents and their parents to one of three groups. One group received multifamily training on family teamwork (MF). For the second group, families received the same content as group 1 plus simulation activities for parents (MF+S). The control group received no education intervention. At the 6-month followup, the MF+S group demonstrated a statistically significant improvement in HbA1c levels compared to the control group (WMD -1.09 percent; 95% CI, -2.11, -0.07). Similarly the MF group also showed improvement in HbA1c levels; however, the results were not statistically significant (WMD -0.31 percent; 95% CI, -1.40, 0.78). The methodological quality of this study was rated as low (1/5 on the Jadad score; unclear allocation concealment).

Laffel et al. ^38^ randomly assigned 105 families to a family-focused teamwork intervention (TW) or to standard care (i.e., routine multidisciplinary clinical care). At the end of the 12-month program, the TW group showed improved HbA1c levels (8.4±1.3 percent at baseline vs. 8.2±1.1 percent) compared to the control group (8.3±1.0 percent at baseline vs. 8.7±1.5 percent). In a multivariable regression analysis that controlled for age, duration of diabetes, and diabetes management, the change in HbA1c level after 1 year was 0.5 percent better in the TW group than in the control group (R^2^ = 0.17, p = 0.04). The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Children with newly diagnosed diabetes. The RCT by Sundelin et al. ^70^ compared conventional inpatient education (n = 19 families) to a multidisciplinary program for family-oriented crisis intervention delivered in an outpatient setting (n = 19 families). There were no statistically significant differences in HbA1c levels between the two groups up to 5 years following diagnosis; both groups demonstrated improved levels in HbA1c levels compared to baseline measures. The mean baseline measure for the intervention group was 9.6±0.14 percent and at 5 years, it was 7.6±15 percent; for the control group, baseline HbA1c level was 9.8±0.74 percent and at 5 years it was 7.2±1.5 percent. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Kennedy-Iwai ^36^ randomly assigned 19 families to receive standard care (standard clinical treatment and diabetes education) or standard care plus a couple communication program delivered to parents. There was no improvement in HbA1c levels at the post-treatment assessment for children in either group. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Children with poorly controlled diabetes. Wysocki et al. ^83^ randomly assigned 119 children to 3 groups: standard care (physician directed clinical therapy), education and support (standard care plus 10 sessions of a diabetes support group), and BFST (standard care plus family problem-solving and communication training and individualized treatment plan). At the end of the 3-month intervention none of the groups demonstrated any significant change from their baseline HbA1c levels. The methodological quality of this study was rated as high (3/5 on the Jadad score; adequate allocation concealment).

In an uncontrolled before-and-after study, Harris et al. ^28^ reported 6-month followup data for 18 adolescents and their families who enrolled in a BFST program. HbA1c levels were unchanged from baseline levels. The methodological quality of this study was rated as weak using the Thomas instrument.

### Skills Training—HbA1c

Description of studies. Six studies (3 RCTs, ^43,^ ^49,^ ^57^ 2 cohorts, ^40,^ ^53^ 1 uncontrolled before-and-after ^11^ ) examined various interventions that focused on skills training. Studies were conducted in the United States, ^11^ Canada, ^49,^ ^57^ Europe, ^43,^ ^53^ and Thailand. ^40^ The median year of publication was 2001 and ranged from 1983 to 2003.

The number of participants enrolled in the studies ranged from 32 to 130 (median = 51 [IQR 39 to 56]). The mean age of participants ranged from 7.1 to 14.4 years. For three studies, the mean age was less than 12 years. ^11,^ ^40,^ ^49^ Two studies examined education interventions delivered to children and their families at the time of diagnosis. ^40,^ ^49^ Two studies focused on children who demonstrated poor metabolic control. ^43,^ ^57^

Most interventions were targeted at children and their parents or the entire family; in one study the intervention was delivered to the child. ^57^ The settings for the interventions were described as a diabetes center, ^49^ hospital inpatient unit, ^40^ or home. ^53^ For three studies, the setting was mixed (e.g., diabetes center and home). ^11,^ ^43,^ ^57^ All studies conducted post-intervention assessments for HbA1c. The median followup period for the studies was 18 months and ranged from 6 to 43.5 months.

### Results

General population of children with diabetes. Nordfeldt and Ludvigsson ^53^ evaluated the effect of self-study material on diabetes education aimed at self-management skills and the prevention of hypoglycemia. Over a 3-year period (1997 to 1999) brochures and videos were distributed to approximately 130 patients and families each year. HbA1c levels were compared to the mean levels for 1996 (prior to the distribution of the brochures). Mean HbA1c levels in 1997 were statistically significantly lower than those reported in 1996 (6.5±1.1 vs. 6.8±1.2 percent, respectively); similar results were reported comparing 1998 and 1996 (6.4±1.1 vs. 6.8±1.2 percent, respectively). The methodological quality of this study was rated as weak using the Thomas instrument.

In an uncontrolled before-and-after study by Caravalho and Saylor, ^11^ 56 children and their parents were taught insulin adjustment procedures and received group support and education to improve self-management. Among the 38 patients who were assessed at 6 months, there was no significant improvement in HbA1c levels from baseline to post-intervention (9.15±2.32 vs. 8.99±1.79 percent). The methodological quality of this study was rated as weak using the Thomas instrument.

Children with newly diagnosed diabetes. Likitmaskul et al. ^40^ conducted a nonconcurrent cohort study to compare the effect of a multidisciplinary team approach to diabetes education to conventional education that focused on insulin injection and how to control diet. The 28 children who received conventional education were diagnosed with diabetes prior to 1996 and served as a historical comparison group to the 24 children who were diagnosed after 1996. The children who received the multidisciplinary education program demonstrated significantly lower levels of HbA1c up to 3 years after diagnosis (12.4±2.7 vs. 13.6±5.4 percent, respectively [p = 0.03]). The methodological quality of this study was rated as moderate using the Thomas instrument.

In the study by Mitchell, ^49^ 32 children were randomly assigned to either the intervention or the control group. The intervention group received standard multidisciplinary education and support plus a booklet targeted at improving compliance with treatment. The control group received standard education and support. The intervention group showed a general trend to lower HbA1c values over the 24-month followup; however, the differences were not statistically significant except at 10 to 13 months post-diagnosis. The methodological quality of this study was rated as low (1/5 on the Jadad score; unclear allocation concealment). Both the intervention and control groups had substantial dropouts over the study period (47 and 53 percent, respectively).

Children with poorly controlled diabetes. Children with poorly controlled diabetes were targeted in the RCT by Mann et al. ^43^ Children in the intervention group (n = 19) received intensive diabetes education combined with regular SMBG. Children in the control group (n = 20) received intensive education only. At the end of the study, there was no significant change in HbA1c levels from baseline to 18 months in either group (14.1±1.3 vs. 14.3±1.9 percent for the intervention group; 12.7±2.0 vs. 12.8±2.4 percent for the control group). The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

In the RCT by Panagiotopoulos et al. ^57^ 25 children received weekly telephone calls and guidance with SMBG, while 25 children received standard care (i.e., routine clinical care). The authors reported that at 6 months, HbA1c levels decreased significantly from baseline in both the intervention and control groups (9.7±1.2 to 8.8±1.3 percent and 9.6±1.3 to 9.1±1.4 percent, respectively). However, the magnitude of change between the two groups was not statistically significant. In a post hoc subgroup analysis of children with HbA1c levels greater than 9.5 percent at baseline, the authors found that HbA1c levels decreased significantly in the intervention group. Six months after study completion, this subset continued to have improved HbA1c levels compared to the control group (from 10.5±1.0 to 9.3±0.9 vs. 10.6±1.0 to 10.4±1.5, respectively). The methodological quality of this study was rated as high (3/5 on the Jadad score; unclear allocation concealment).

### Diabetes Camp—HbA1c

Description of studies. In five studies (1 RCT, ^46^ 2 CCTs, ^62,^ ^84^ 2 uncontrolled before-and-after studies ^34,^ ^35^ ) the education intervention was delivered as part of a diabetes camp program. Four studies were conducted in the United States and one took place in Europe. ^34^ The median year of publication was 1997 and ranged from 1986 to 2005.

The number of participants enrolled in the studies ranged from 25 to 237 (median = 42 [IQR 33 to 56]). The mean age of participants ranged from 10.0 to 14.5 years. In two studies, the mean age was less than 12 years. ^35,^ ^84^ One study focused on children who demonstrated poor metabolic control. ^34^ All interventions were delivered to the children. All studies conducted post-intervention assessments for HbA1c; the median followup period was 3.5 months and ranged from 3 to 12 months.

### Results

General population of children with diabetes. The specific interventions that were delivered during the diabetes camps were diverse. In the trial by Massouh et al., ^46^ 34 adolescents were randomly assigned to a group that received a daily 1-hour teaching session about diabetes or to a group that received the lecture plus a social learning intervention (relationship skills) that involved role playing. Both groups demonstrated increases (i.e., poorer control) in HbA1c levels at 3.5 months following the end of camp (1.5 percent [p = 0.008] for the intervention group; 1.2 for the comparison group [p = 0.14]). The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Remley ^62^ conducted a CCT to compare a social cognitive theory-based program with a standard non-theory based camp education program. Eight 1-week camps across the United States were designated deliver the either the theory-based intervention or the standard program. At the 3-month followup, there was no significant change in HbA1c levels for either group. The attrition rate for both groups was high (40 percent). The methodological quality of this study was rated as low (1/3 on the modified Jadad score; unclear allocation concealment).

Zorumski ^84^ investigated the effects of self-care training for 49 children. All children received basic self-care training from their physicians; 27 also attended a 1-week day camp that provided additional self-care instruction. At the 4-month followup, there was no significant change from baseline HbA1c levels for either group (9.93±2.9 vs. 10.49±2.7 percent [intervention group] and 10.85±2.14 vs. 10.47±2.8 percent [comparison group]). The methodological quality of this study was rated as low (0/3 on the modified Jadad score).

In an uncontrolled before-and-after study Kemp et al. ^35^ assessed the effectiveness of diabetes education and carefully monitored blood glucose control among 42 children who attended a 2-week summer camp. One year later, HbA1c levels had increased (i.e., poorer control) from the baseline measure (8.1±1.9 vs. 10.1±1.9 percent). The methodological quality of this study was rated as weak using the Thomas instrument.

Children with poorly controlled diabetes. In an uncontrolled before-and-after study (n = 25), Karaguzel et al. ^34^ examined the effect of a 1-week diabetes camp that incorporated intensive insulin treatment into a general diabetes program (n = 25). There was a statistically significant decrease in HbA1c levels from baseline to 12-months post-intervention (9.3±2.5 vs. 8.2±1.5 percent, p<0.05). The methodological quality of this study was rated as weak using the Thomas instrument.

### Other Interventions—HbA1c

General population of children with diabetes. Campaigne et al. ^10^ assessed the effects of physical training on HbA1c levels. Fourteen adolescents were randomly assigned to either a 12-week exercise program or to a control group that did not modify the usual exercise routine. At the end of the program, HbA1c levels remained unchanged in both groups. The methodological quality of the study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

The RCT by Olmsted et al. ^56^ evaluated the effect of a 6-session intervention for eating disorders for young women with disturbed eating habits. Eighty-five patients were randomized to the psychoeducation program or to routine care at the diabetes center. At the 6-month followup neither group demonstrated any significant improvement in HbA1c levels. The methodological quality of the study was moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

Children with poorly controlled diabetes. In a CCT, Moran et al. ^51^ compared two equivalent groups of 11 children with a history of poor metabolic control. One group received an intensive inpatient psychotherapy program; the comparison group comprised children who were admitted to hospital for medical treatment of diabetes-related complications. Both groups received diabetes education while in hospital. HbA1c levels were significantly improved at the 12-month followup for the intervention group (14.3 vs. 11.5 percent); there was no change in HbA1c levels for the comparison group (13.7 vs. 13.5 percent). The methodological quality of the study was low (0/3 on the modified Jadad score).

### Summary of Results—HbA1c

Overall, we identified 52 studies that assessed the effectiveness of diabetes education programs in controlling HbA1c levels (Table 6). Of these, 30 studies (19 RCTs, 3 CCTs, 3 cohorts, 5 uncontrolled before-and-after) examined the general population of children with type 1 diabetes, 8 (5 RCTs, 1 CCT, 2 cohorts) focused on children with newly diagnosed diabetes, and 14 (9 RCTs, 3 CCTs, 2 uncontrolled before-and-after) considered children with poorly controlled diabetes. Due to substantial differences across studies in terms of population, interventions, comparison groups, duration of intervention, and followup time points, we were not able to pool the results of any of the studies.

Table 6 Summary of results for studies assessing the effect of diabetes education on HbA1c

Author Year | Intervention | Study design Sample size | Quality | Conclusion
General population of children with diabetes
Anderson ^6^ 1989 | Cognitive behavioral therapy | RCT 70 | Low | IG had significantly lower HbA1c than CG at 18 mo.
Anderson ^5^ 1999 | Cognitive behavioral therapy | RCT (3 arms) 89 | Low | IG had lower HbA1c than CG at 24 mo.; the difference between groups was NS
Barglow ^7^ 1983 | Cognitive behavioral therapy | CCT 42 | Low | HbA1c levels decreased for both groups at 4 mo.; difference between groups was NS
Brown ^9^ 1997 | General diabetes education | RCT 59 | Low | No significant improvement for either group at 6 mo.
Campaigne ^10^ 1985 | Physical training | RCT 16 | Low | No significant change for either group at 12 wk.
Caravalho ^11^ 2000 | Skills | Before-after 56 | Low | No significant change in HbA1c at 6 mo.
Grey ^21^ 2000 | Cognitive behavioral therapy | RCT 77 | Moderate | IG had significantly lower HbA1c than CG at 12 mo.
Gross ^22^ 1985 | Cognitive behavioral therapy | RCT 14 | Low | HbA1c levels decreased for both groups at 6 mo.; difference between groups was NS
Hackett ^24^ 1989 | General diabetes education | RCT (4 arms) 119 | Low | No significant change for any of the groups at 8 mo.
Horan ^31^ 1990 | Cognitive behavioral therapy | RCT 20 | Low | No significant change in HbA1c for either group at 15 wk.
Howe ^32^ 2005 | General diabetes education | RCT (3 arms) 89 | Low | HbA1c levels decreased for all groups at 6 mo.; differences between groups were NS
Kaplan ^33^ 1985 | Cognitive behavioral therapy | RCT 21 | Low | IG had significantly lower HbA1c than CG at 4 mo.
Kemp ^35^ 1986 | Diabetes camp | Before-after 42 | Low | No significant improvement in HbA1c at 12 mo.
Laffel ^38^ 2003 | Family therapy | RCT 105 | Low | IG had significantly lower HbA1c than CG at 12 mo.
Lawson ^39^ 2000 | General diabetes education | Cohort 28 | Low | HbA1c levels decreased in IG at 12 mo.; no change for comparison group; however, groups had baseline differences
Massouh ^46^ 1989 | Diabetes camp | RCT 33 | Low | No significant improvement in HbA1c for either group at 3.5 mo.
McNabb ^47^ 1994 | Cognitive behavioral therapy | RCT 24 | Low | HbA1c levels decreased for both groups at 6 wk.; difference between groups was NS
Nordfeldt ^54^ 1999 | Cognitive behavioral therapy | Cohort 139 | Low | 1994-5 cohort (IG) had significantly lower HbA1c than 1980-1 cohort
Nordfeldt ^53^ 2002 | Skills | Cohort 130 | Low | 1997 and 1998 cohorts (IG) had significantly lower HbA1c than the1996 cohort
Olmsted ^56^ 2002 | Psychoeducation | RCT 85 | Moderate | No significant change for either group at 6 mo.
Povlsen ^61^ 2005 | General diabetes education | Before-after 37 | Low | Significant decrease in HbA1c immediately after intervention; no change at 3 and 6 mo.
Remley ^62^ 1999 | Diabetes camp | CCT 237 | Low | No significant change in HbA1c for either group at 3 mo.
Satin ^63^ 1989 | Family therapy | RCT (3 arms) 32 | Low | IG had significantly lower HbA1c than CG at 6 mo.
Szumowski ^72^ 1990 | Cognitive behavioral therapy | RCT 27 | Moderate | No significant change in HbA1c for either group at 3 mo.
Verrotti ^75^ 1993 | General diabetes education | Before-after 30 | Moderate | Significant decrease in HbA1c at 12 mo.
von Sengbusch ^77^ 2006 | General diabetes education | Before-after 107 | Moderate | No significant change in HbA1c at 12 mo.
Wadham ^79^ 2005 | General diabetes education | RCT 67 | Low | No significant change in HbA1c for either group at 6 mo.
Webb ^80^ 1999 | Cognitive behavioral therapy | RCT 66 | Low | No significant change in HbA1c for either group at 3 mo.
Wysocki ^82^ 2007 | Family therapy | RCT (3 arms) 104 | Low | IG had significantly lower HbA1c than either CG at 12 mo.
Zorumski ^84^ 1997 | Diabetes camp | CCT 56 | Low | No significant change in HbA1c for either group at 4 mo.
Children with newly diagnosed diabetes
Delamater ^17^ 1990 | Cognitive behavioral therapy | RCT (3 arms) 36 | Moderate | IG had significantly lower HbA1c than both CG at 24 mo.
Dougherty ^18^ 1999 | General diabetes education | RCT 63 | Moderate | HbA1c levels decreased for both groups at 3 mo.; differences still present at 36 mo.; IG had significantly lower HbA1c compared to CG at 24–36 mo.
Golden ^19^ 1985 | Cognitive behavioral therapy | CCT 19 | Low | HbA1c levels were significantly lower for IG than CG over 15 mo.; no data provided to assess the change from baseline for HbA1c
Kennedy-Iwai ^36^ 1991 | Family therapy | RCT 19 | Low | No significant change in HbA1c for either group at 3 mo.
Likitmaskul ^40^ 2002 | Skills | Cohort 52 | Moderate | Post-1996 cohort (IG) had significantly lower HbA1c than the pre-1996 cohort over 3 yr.
Mitchell ^49^ 1996 | Skills | RCT 32 | Low | HbA1c levels were lower for IG than CG over 24 mo.; difference between groups was NS except at 10–13 mo.
Srinivasan ^69^ 2004 | General diabetes education | Cohort 110 | Moderate | No significant change in HbA1c in either cohort at 3, 6 and 12 mo.
Sundelin ^70^ 1996 | Family therapy | RCT 38 | Low | HbA1c levels decreased for both groups up to 5 yr.; differences between groups were NS
Children with poorly controlled diabetes
Boardway ^8^ 1993 | Cognitive behavioral therapy 77 | RCT 31 | Low | No significant change in HbA1c for either group at 6 mo.
Cigrang ^13^ 1992 | Cognitive behavioral therapy | RCT (3 arms) 37 | Low | HbA1c levels decreased for all groups at 3 mo.; differences among groups were NS
Couper ^14^ 1999 | Cognitive behavioral therapy | CCT 69 | Low | HbA1c levels decreased in IG at 6 and 18 mo.; no change in CG
Coupland ^15^ 1992 | General diabetes education | RCT 32 | Low | Significant decreases at 6 mo. in both groups; difference between groups was NS
Delamater ^16^ 1991 | Cognitive behavioral therapy | RCT (3 arms) 13 | Low | No significant change in HbA1c for either group at 4 mo.
Hains ^25^ 2000 | Cognitive behavioral therapy | RCT 15 | Low | No significant change in HbA1c for either group at 1 mo.
Harris ^28^ 2005 | Family therapy | Before-after 18 | Low | No significant change in HbA1c at 6 mo.
Karaguzel ^34^ 2005 | Diabetes camp | Before-after 25 | Low | Significant decrease in HbA1c at 6 and 12 mo.
Mann ^43^ 1984 | Skills training | RCT 39 | Low | No significant change in HbA1c for either group at 18 mo.
Moran ^51^ 1991 | Psychoeducation | CCT 22 | Low | HbA1c levels decreased in IG at 12 mo.; no change in CG
Nunn ^55^ 2006 | General diabetes education | RCT 123 | High | No significant change at 8 mo. for either group
Panagiotopoulos ^57^ 2003 | Skills | RCT 50 | High | HbA1c levels decreased for both groups at 6 mo.; difference between groups was NS
Viner ^76^ 2003 | Cognitive behavioral therapy | CCT 21 | Low | IG had significantly lower HbA1c than CG at 12 mo.
Wysocki ^83^ 2000 | Family therapy | RCT (3 arms) 119 | High | No significant change in HbA1c for either group at 3 mo.

CG = control group; IG = intervention group; NS = not significant

General population of children with diabetes. Overall, 30 studies (19 RCTs, ^5,^ ^6,^ ^9,^ ^10,^ ^21,^ ^22,^ ^24,^ ^31^ – ^33,^ ^38,^ ^46,^ ^47,^ ^56,^ ^63,^ ^72,^ ^79,^ ^80,^ ^82^ 3 CCTs, ^7,^ ^62,^ ^84^ 3 cohorts, ^39,^ ^53,^ ^54^ 5 uncontrolled before-and-after ^11,^ ^35,^ ^61,^ ^75,^ ^77^ ) assessed the effectiveness of diabetes education in controlling HbA1c levels in the general population of children with diabetes (Table 6). Interventions that were assessed included general diabetes education, ^9,^ ^24,^ ^32,^ ^39,^ ^61,^ ^75,^ ^77,^ ^79^ cognitive behavioral therapy, ^5^ – ^7,^ ^21,^ ^22,^ ^31,^ ^33,^ ^47,^ ^54,^ ^72,^ ^80^ family therapy, ^38,^ ^63,^ ^82^ skills training, ^11,^ ^53^ diabetes camp, ^35,^ ^46,^ ^62,^ ^84^ physical training, ^10^ and psychoeducation. ^56^ Overall the methodological quality of the studies was low. Three RCTs were rated as moderate (Grey et al., ^21^ Olmsted et al., ^56^ and Szumowski ^72^ ) and two uncontrolled before-and-after studies (Verrotti, ^75^ von Sengbusch et al. ^77^ ) were assessed as moderate.

### Results

The results of the studies rated as moderate quality were mixed. Grey et al. ^21^ found that the intervention group that received intensive diabetes management plus coping skills training had significantly lower HbA1c levels than the group that received intensive management only. Szumowski ^72^ found no change from baseline levels of HbA1c for the intervention group that received goal setting training or the control group. Similarly, Olmsted et al. ^56^ reported no difference in HbA1c levels among diabetic patients with eating disorders comparing a psychoeducation intervention with routine care. The uncontrolled before-and-after study by Verrotti et al. ^75^ found decreased levels of HbA1c among teenagers who received general diabetes education. In contrast, the uncontrolled before-and-after study by von Sengbusch et al. ^77^ assessed a mobile diabetes education program and found no change in HbA1c following the intervention.

The results of the remaining studies were inconsistent. Seven studies ^6,^ ^33,^ ^38,^ ^53,^ ^54,^ ^63,^ ^82^ reported that HbA1c levels decreased significantly following the diabetes education intervention. Three of these studies assessed cognitive behavioral therapy, ^6,^ ^33,^ ^54^ three studies assessed family therapy programs ^38,^ ^63,^ ^83^ and one assessed skills training. ^53^ Six studies ^5,^ ^7,^ ^22,^ ^32,^ ^47,^ ^61^ found that HbA1c levels improved significantly for both the intervention and control groups; however, the differences between groups were not statistically significant. Four of these studies assessed cognitive behavioral therapy ^5,^ ^7,^ ^22,^ ^47^ and two assessed general diabetes education. ^32,^ ^61^ The remaining studies ^9^ – ^11,^ ^24,^ ^31,^ ^35,^ ^46,^ ^62,^ ^79,^ ^80,^ ^84^ reported that diabetes education had no significant effect on improving HbA1c levels.

### Children With Newly Diagnosed Diabetes

Overall, 8 studies (5 RCTs, ^17,^ ^18,^ ^36,^ ^49,^ ^70^ 1 CCT, ^19^ 2 cohorts ^40,^ ^69^ assessed the effectiveness of diabetes education among children with newly diagnosed diabetes (Table 6). Interventions that were assessed were general diabetes education, ^18,^ ^69^ cognitive behavioral therapy, ^17,^ ^19^ family therapy, ^36,^ ^70^ skills training. ^40,^ ^49^ In general, the methodological quality was low; two RCTs (Delamater et al. ^17^ and Dougherty et al. ^18^ ) and the two cohort studies (Likitmaskul et al. ^40^ and Srinivasan et al. ^69^ ) were assessed as being of moderate quality.

Results. Three studies (Dougherty et al., ^18^ Sundelin et al., ^70^ Srinivasan et al. ^69^ compared general diabetes education programs ^18,^ ^69^ or family therapy programs ^70^ that were delivered in an ambulatory setting vs. the same program to delivered during hospitalization. The findings of the studies were inconsistent (Table 6). Dougherty et al. ^18^ reported that the decrease in HbA1c levels was significantly greater for the home-based group compared with the inpatient group. Sundelin et al. ^70^ and Srinivasan et al. ^69^ found no significant differences in HbA1c levels between groups.

The RCT by Delamater et al. ^17^ found that self-management training group had significantly lower HbA1c levels compared with the control group. Similarly, the cohort study by Likitmaskul et al. ^40^ ) found that HbA1c levels were significantly lower in the cohort that received skills training. Mitchell ^49^ assessed skills training and reported that HbA1c levels improved significantly for both the intervention and control groups; however, the difference was not statistically significant. The sample size was small and there may not have been sufficient statistical power to detect a difference. The remaining study that assessed a family therapy program delivered to parents ^36^ reported that diabetes education had no significant effect on improving HbA1c levels in children with newly diagnosed diabetes.

### Children With Poorly Controlled Diabetes

Overall, 14 studies (9 RCTs, ^8,^ ^13,^ ^15,^ ^16,^ ^25,^ ^43,^ ^55,^ ^57,^ ^83^ 3 CCTs, ^14,^ ^51,^ ^76^ 2 uncontrolled before-and-after ^28,^ ^34^ ) assessed the effectiveness of diabetes education among children with poorly controlled diabetes (Table 6). Interventions that were assessed included general diabetes education, ^15,^ ^55^ cognitive behavioral therapy, ^8,^ ^13,^ ^14,^ ^16,^ ^76^ family therapy, ^28,^ ^83^ skills training, ^43^ diabetes camp, ^34^ and psychoeducation. ^51^ In general, the methodological quality of the studies was low; three RCTs were assessed as being of high quality (Nunn et al., ^55^ Panagiotopoulos et al., ^57^ Wysocki et al. ^83^ ).

Results. Two large high-quality RCTs that assessed general diabetes education (Nunn et al., ^55^ ) and family therapy (Wysocki et al. ^83^ ) reported that diabetes education had no significant impact on HbA1c levels. The RCT by Panagiotopoulos et al. ^57^ found HbA1c levels decreased for both groups, but the difference was not significant.

The results of the remaining studies were inconsistent. Four studies ^14,^ ^51,^ ^76^ reported that HbA1c levels decreased significantly following the diabetes education intervention. Two RCTs ^13,^ ^15^ found that HbA1c levels improved significantly for both the intervention and control groups; however, the differences were not statistically significant. Both studies had small samples (less than 40 participants each) and may not have had sufficient statistical power to detect a difference. The remaining studies ^8,^ ^16,^ ^25,^ ^28,^ ^43^ reported that diabetes education had no significant effect on improving HbA1c levels in this patient population.

## Health Services Utilization

Overall, we identified 11 studies that assessed the impact of diabetes education on health service utilization. Health service utilization was measured in a variety of ways: length of stay, hospital or ED admissions for diabetes- and non-diabetes-related complications. Of the 11, 4 examined the general population of children with diabetes, 4 focused on children with newly diagnosed diabetes and 3 targeted children with poorly controlled diabetes.

### General Diabetes Education—Health Services Utilization

Description of studies. We identified 6 studies (3 RCTs, ^9,^ ^55,^ ^71^ 2 cohorts, ^41,^ ^66^ 1 uncontrolled before-and-after ^77^ ) that assessed the effect of general diabetes education programs on health service utilization. Studies were conducted in the United States, ^9,^ ^41,^ ^66,^ ^71^ Australia ^55^ and Europe. ^77^ The median year of publication was 2001 and ranged from 1988 to 2006.

The number of participants in the studies ranged from 30 to 301 (median = 83 [IQR 32 to 146]). The mean age of participants ranged from 7.4 to 11.9 years (n = 5 studies). Two studies focused on children with newly diagnosed diabetes. ^41,^ ^66^ One study examined an education intervention delivered to children who demonstrated poor metabolic control. ^55^

Five of the intervention programs targeted children and their parents or the family; one was delivered to children only. ^9^ The settings for interventions were described as a hospital inpatient unit, ^41,^ ^77^ diabetes center, ^71^ home, ^9^ or mixed (e.g., diabetes center and home). ^55,^ ^66^ Three studies reported post-intervention assessments of 1 month, ^66^ 6 months ^77^ and 24 months. ^71^

### Results

General population of children with diabetes. Svoren et al. ^71^ randomly assigned 299 patients to one of three groups: a case manager or “care ambassador” whose role was to monitor clinic attendance and provide telephone outreach to families (CA), a care ambassador plus eight psychoeducational modules on diabetes care that were delivered during visits to the diabetes clinic (CA+), or standard care (routine clinical care). At the end of the 24-month program, the CA+ group had a significantly lower rate of hospitalizations than the combined comparison groups (8.9 per 100 patient-years vs. 15.3 per 100 patient-years, respectively [p = 0.04]). The rate of emergency department (ED) visits was also lower in the CA+ group than for the comparison groups (21.0 per 100 patient-years vs. 34.9 per 100 patient-years, respectively [p = 0.004]). The methodological quality of the study was moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

Brown et al. ^9^ randomly assigned 59 children and adolescents to a group that played a video game featuring characters with diabetes or a group that played a pinball video game with no information on diabetes. At the end of the 6-month study period, the number of unscheduled urgent visits to the physician for diabetes-related problems declined in the intervention group (0.57 visits per child vs. 0.13 visits). For the comparison group, the number of visits increased (0.61 visits per child vs. 0.64). However, the difference in the change from baseline for the two groups was not statistically significant (p = 0.08). The methodological quality of the study was low (1/5 on the Jadad score; unclear allocation concealment).

In an uncontrolled before-and-after study, von Sengbusch et al. ^77^ assessed the impact of a mobile diabetes education service in a group of 107 children living in rural areas. At 24 months, the number of hospitalizations decreased significantly from 17 (16.2 percent) at baseline to 7 (6.8 percent). The methodological quality of the study was moderate based on the Thomas instrument.

Children with newly diagnosed diabetes. In a retrospective cohort study (n = 30), Lipman ^41^ compared the effect of diabetes education delivered by a clinical nurse specialist compared to the same program delivered by staff nurses. The authors reported that the length of hospitalization was significantly shorter for the intervention group than for the comparison group. (6.2±1.8 days vs. 8.4±1.8 days,[p<0.01], respectively). The methodological quality of the study was moderate based on the Thomas instrument.

In a prospective cohort study, Siminerio et al. ^66^ examined differences between outpatient and inpatient programs for newly diagnosed children (n = 32). In the month following diagnosis, none of the children in either group reported any diabetes-related hospital or ED visits. The methodological quality of the study was moderate based on the Thomas instrument.

Children with poorly controlled diabetes. Nunn et al. ^55^ randomly assigned 123 patients to receive telephone calls from a pediatric diabetes educator or standard care (i.e., routine clinic visits but no telephone calls). Over the course of the 8-month study, both groups showed an increase in hospitalizations of 0.02 per year; however, the difference in the change from baseline between the groups was not statistically significant (p = 0.57). The methodological quality of the study was high (3/5 on the Jadad score; unclear allocation concealment).

### Cognitive Behavioral Therapy—Health Services Utilization

Children with newly diagnosed diabetes. One CCT by Golden et al. ^19^ examined the effect of an intervention that used cognitive behavioral therapy techniques. Eleven families received an integrated diabetes education and psychosocial support program that was delivered in a motel-like setting. The comparison group (n = 8) received the same training 15 months after diagnosis. Over 24 months following diagnosis, the intervention group experienced 1 hospitalization for hypoglycemia compared with 11 hospitalizations for the comparison group. The methodological quality of the study was low (1/3 on the modified Jadad score).

### Skills Training—Health Services Utilization

Children with newly diagnosed diabetes. Likitmaskul et al. ^40^ conducted a nonconcurrent cohort study to compare the effect of a multidisciplinary team approach to diabetes education to conventional education that focused on insulin injection and how to control diet. The 28 children who received conventional education were diagnosed with diabetes prior to 1996 and served as a historical comparison group to the 24 children who were diagnosed after 1996. Based on a review of medical records, the hospital length of stay after initial diagnosis was significantly shorter for children who received the multidisciplinary education program than for the comparison group (17.6±9.5 days vs. 36.0±46.5 days, respectively). The methodological quality was rated as moderate using the Thomas instrument.

Children with poorly controlled diabetes. In the RCT by Mann et al. ^43^ children in the intervention group (n = 19) received intensive diabetes education combined with regular SMBG; children in the control group (n = 20) received intensive education only. Over the 18-month followup, the group that received education only had 4 diabetes-related hospital admissions; the SMBG group reported no admissions (p< 0.04). The methodological quality of the study was low (2/5 on the Jadad score; unclear concealment of allocation).

### Diabetes Camp—Health Services Utilization

General population of children with diabetes. In an uncontrolled before-and-after study, Koontz ^37^ examined the effect of a general diabetes education program delivered at a 1-week camp (n = 112). The mean age of the children was 5.0 years. At the 3-month followup, there were no hospitalizations reported for the 29 children who responded to the followup questionnaire. Three children reported physician visits for reasons other than their regular checkup. No baseline data were provided, therefore we do not know if this was different from their pre-camp experience. The methodological quality of the study was rated as moderate based on the Thomas instrument.

### Other Interventions—Health Services Utilization

Children with poorly controlled diabetes. In the CCT by Moran et al. ^51^ a group of 11 children received an intensive inpatient psychotherapy program; the comparison group comprised 11 children who were admitted to hospital for medical treatment of diabetes-related complications. Both groups received diabetes education while in hospital. At the 12-month followup there was no significant difference in the number of overall hospitalizations (1.0±1.4 admissions per child vs. 0.9±0.9 [comparison group]). When the number of diabetes-related hospital admissions was compared, the intervention group had significantly fewer admissions than the comparison group (0.3±0.5 admissions per child vs. 0.9±0.9 [p<0.05], respectively). The methodological quality of the study was low (0/3 on the modified Jadad score).

### Summary of Results—Health Services Utilization

We identified 11 studies that assessed the impact of diabetes education on health services utilization (Table 7). Of these, four studies (2 RCTs, 2 uncontrolled before-and-after) examined the general population of children with type 1 diabetes, four (1 CCT, 3 cohort) focused on children with newly diagnosed diabetes, and three (2 RCTs, 1 CCT) considered children with poorly controlled diabetes. Health services utilization was measured in a variety of ways: length of stay, hospital or ED admissions for diabetes- and non-diabetes-related complications.

Table 7 Summary of results for studies assessing the effect of diabetes education on health services utilization

Author Year | Intervention | Study design Sample size | Quality | Conclusion
General population of children with diabetes
Brown ^9^ 1997 | General diabetes education | RCT 59 | Low | IG reported fewer physician visits while CG visits increased at 6 mo.; difference was NS
Koontz ^37^ 2002 | Diabetes camp | Before-after 112 | Moderate | No hospitalizations or physician visits reported at 3 mo.; however, no baseline data were provided
Svoren ^71^ 2003 | General diabetes education | RCT (3 arms) 299 | Moderate | IG had significantly fewer hospital and ED admissions than either CG at 24 mo.
von Sengbusch ^77^ 2006 | General diabetes education | Before-after 107 | Moderate | Number of hospitalizations decreased significantly at 24 mo.
Children with newly diagnosed diabetes
Golden ^19^ 1985 | Cognitive behavioral therapy | CCT 19 | Low | IG had significantly fewer hospital admissions than CG at 24 mo.
Likitmaskul ^40^ 2002 | Skills training | Cohort 52 | Moderate | LOS for initial hospitalization was significantly shorter for IG compared to CG
Lipman ^41^ 1988 | General diabetes education | Cohort 30 | Moderate | LOS for initial hospitalization was significantly shorter for IG compared to CG
Siminerio ^66^ 1999 | General diabetes education | Cohort 32 | Moderate | No reported diabetes-related hospital or ED admissions for either group at 1 mo.
Children with poorly controlled diabetes
Mann ^43^ 1984 | Skills training | RCT 39 | Low | IG had significantly fewer diabetes-related hospital admissions than CG at 18 mo.
Moran ^51^ 1991 | Psychoeducation | CCT 22 | Low | IG had significantly fewer diabetes-related hospital admissions at 12 mo.
Nunn ^55^ 2006 | General diabetes education | RCT 123 | High | IG and CG reported increased rates of hospitalization at 8 mo.; difference was NS

CG = control group; DCCT = Diabetes Control and Complications Trial; ED = emergency department; IG = intervention group; LOS = length of stay; NS = not significant

General population of children with diabetes. Four studies (2 RCTs, ^9,^ ^71^ 2 uncontrolled before-and-after ^37,^ ^77^ ) assessed the effect of diabetes education on health services utilization in the general population of children with diabetes (Table 7). Three studies assessed general diabetes education programs ^9,^ ^71,^ ^77^ and one assessed a diabetes camp program. ^37^ In general, the methodological quality of the studies was moderate; only one RCT ^9^ was rated as being of low quality.

Results. There is some evidence that diabetes education has an impact on health services utilization in this patient population. The RCT by Svoren et al. ^71^ reported hospital and ED admissions were significantly reduced in the intervention group that were supported by a case manager plus psychoeducation training. The uncontrolled before-and-after study by von Sengbusch et al. ^77^ reported statistically significant reductions in hospital admissions following the intervention. The study by Koontz ^37^ did not report baseline information; however, there were no hospital or ED admissions 3 months following the diabetes camp. The RCT by Brown et al. ^9^ reported a non-significant reduction in physician visits.

Children with newly diagnosed diabetes. Four studies (1 CCT, ^19^ 3 cohorts ^40,^ ^41,^ ^66^ ) assessed the effect of diabetes education on health service utilization among children with newly diagnosed diabetes (Table 7). Overall, the methodological quality of the studies was moderate, with all but one ^19^ rated as moderate quality. Two cohort studies assessed a skills training program (Likitmaskul et al. ^40^ ) and a general diabetes education program (Lipman et al. ^41^ ); both found that the length of stay for initial hospitalization was shorter for the intervention groups than the comparison groups. The cohort study by Siminerio et al. ^66^ compared inpatient vs. ambulatory delivery of general diabetes education and reported that neither study group had any diabetes-related hospital or ED admissions. The RCT by Golden et al. ^19^ reported significantly fewer hospital admissions for the intervention group.

Children with poorly controlled diabetes. The large high-quality RCT by Nunn et al, ^55^ reported increased rates of hospital admission for both the intervention group that received general diabetes education plus telephone followup and the control group (i.e., the intervention was not effective) (Table 7). In contrast, the two studies of low methodological quality ^43,^ ^51^ reported that their intervention groups had significantly fewer hospital admissions than the control groups.

## Complications

Overall, we identified 15 studies that assessed the effectiveness of diabetes education in controlling complications. While one of the objectives of this evidence report was to assess the effect of diabetes education on both long- and short-term complications, all of the complications reported in the included studies were short-term. Of the 15 identified studies, 11 looked at the general population of children with diabetes, 3 focused on children with newly diagnosed diabetes and 1 examined children with poorly controlled diabetes.

### General Diabetes Education—Complications

Description of studies. We identified 6 studies (2 RCTs, ^18,^ ^71^ 1 retrospective cohort, ^39^ 3 uncontrolled before-and-after ^61,^ ^75,^ ^77^ ) that assessed the effect of general diabetes education programs on short-term complications. Studies were conducted in the United States, ^71^ Canada, ^18,^ ^39^ and Europe. ^61,^ ^75,^ ^77^ The median year of publication was 2001 and ranged from 1993 to 2006.

The number of participants in the studies ranged from 28 to 301 (median = 50 [IQR 30 to 107]). The mean age of participants ranged from 9.8 to 15.8 years (n = 5 studies). For three studies, the mean age was less than 12 years. ^18,^ ^71,^ ^77^ One study examined education intervention delivered to children and their families at the time of diagnosis. ^18^

All interventions were targeted to children and their parents or to the family. The settings for interventions were described as a hospital inpatient unit, ^61,^ ^77^ diabetes center, ^71^ or mixed (e.g., diabetes center and home). ^18,^ ^39^ The setting was not clearly described in one study. ^75^ All six studies reported post-intervention assessments; the median followup period was 12 months and ranged from 6 to 36 months.

### Results

General population of children with diabetes. Svoren et al. ^71^ randomly assigned 299 patients to one of three groups: a case manager or “care ambassador” whose role was to monitor clinic attendance and provide telephone outreach to families (CA), a care ambassador plus eight psychoeducational modules on diabetes care that were delivered during visits to the diabetes clinic (CA+), or standard care (routine clinical care). At the end of the 24-month program, the CA+ group had significantly reduced rates of severe hypoglycemic events compared with either the CA or standard care group (0.45 events per person-year vs. 0.56 events or 0.65 events, respectively [p = 0.02]). The methodological quality of the study was moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

The retrospective cohort study (n = 28) by Lawson et al. ^39^ compared intensive, individualized education to group education delivered to patients. The content for both interventions was the same. After 12 months, two children (12 percent) in the intervention group experienced severe hypoglycemic reactions; there were no severe reactions in the comparison group. The difference was not statistically significant (p = 0.13). There were no episodes of DKA in either group. The methodological quality of the study was weak based on the Thomas instrument.

Povlsen et al. ^61^ assessed the effect of an intervention targeted on 37 families from ethnic minority groups in Denmark. The intervention included adapted educational material and guidelines and re-education that focused on increasing knowledge and self-care. The authors observed that the number of severe hypoglycemia episodes increased from 3 to 10; however, the increase was not statistically significant. There was one DKA event during the intervention. The methodological quality of the study was weak based on the Thomas instrument.

In an uncontrolled before-and-after study Verrotti et al. ^75^ studied 30 adolescents who attended nine education sessions on general diabetes management. At the 12-month followup, the number of severe hypoglycemia episodes decreased significantly from 2.9±2.2 events to 1.1±1.3 events (p = 0.002). The methodological quality of the study was moderate based on the Thomas instrument.

In an uncontrolled before-and-after study, von Sengbusch et al. ^77^ assessed the impact of a mobile diabetes education service in a group of 107 children. At the 6-month followup the number of episodes of severe hypoglycemia did not change significantly from baseline measures (0.23 events per 100 patient-years to 0.21 events). The methodological quality of the study was moderate based on the Thomas instrument.

Children with newly diagnosed diabetes. Dougherty et al. ^18^ randomly assigned 63 newly diagnosed patients to a 24-month home-based diabetes education program or to traditional hospitalization and outpatient followup. Treatment differences between the groups included duration of initial hospital stay, timing of initial teaching, and the nature and extent of subsequent nursing followup. Over the 24-month followup period, the authors reported no statistically significant differences between the groups in the number or rate of diabetes-related adverse events (severe hypoglycemia, hyperglycemia and ketosis, DKA, chronic hyperglycemia). The rate in the home-based group was 0.34 events per patient compared with 0.26 in the hospital-based group (RR = 1.45 [95% CI: 0.59 to 3.6]). The methodological quality of the study was moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

### Cognitive Behavioral Therapy—Complications

Description of studies. We identified four studies (2 RCTs, ^21,^ ^72^ 1 CCT, ^19^ 1 prospective cohort ^54^ ) that examined the effect of interventions that used cognitive behavioral therapy techniques. Studies were conducted in the United States ^19,^ ^21,^ ^72^ and Europe. ^54^ The median year of publication was 1995 and ranged from 1985 to 2000.

The median number of participants in the studies was 52 and ranged from 27 to 139. The mean age of participants ranged from 2.7 to 14.7 years. For two studies, the mean age was less than 12 years. ^19,^ ^72^ One study examined education intervention delivered to children and their families at the time of diagnosis. ^19^

Interventions were delivered to children, ^21^ parents, ^19^ or to both parents and children or the entire family. ^54,^ ^72^ The settings for interventions were described as an outpatient clinic, ^72^ or mixed (e.g., diabetes center and home). ^21,^ ^72^ The setting was not clearly described in one study. ^19^ All but one study ^19^ reported post-intervention assessments; the followup periods were 3 months, ^72^ 12 months, ^21^ and 248 patient years. ^54^

### Results

General population of children with diabetes. Grey et al. ^21^ randomly assigned 77 adolescents to receive intensive diabetes management (IDM) as described in the DCCT or IDM plus a behavioral program of coping skills training intervention (IDM+). At the 12-month followup, the IDM+ group reported statistically lower rates for adverse events than the control group (severe hypoglycemia: 1.1 per patient year vs. 1.2 per patient year, respectively [p<0.001]; DKA: 0.02 vs. 0.06 events per patient year, respectively [p<0.001]). The authors observed that the incidence of hypoglycemia significantly decreased in females but not in males in the IDM+ group. Overall, the rate of complications was higher than that reported by the DCCT. The methodological quality of the study was moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

In a prospective study with historical controls, Nordfeldt and Ludvigsson ^54^ examined the effect of multiple dose insulin therapy combined with problem-based training and psychosocial support. The prospective cohort comprised 248 children admitted to hospital in 1994 and 1995. The comparison group (156 patients admitted in 1980-81) received standard clinical care. The annual incidence of severe hypoglycemia with unconsciousness was 0.17 events per patient-year for the intervention group compared with 0.23 events per patient-year for the 1980-81 cohort (p<0.05). The incidence of DKA requiring hospitalization during 1994-95 was 0.015 episodes per patient-year (not reported for the 1980-81 cohort). The methodological quality of the study was weak based on the Thomas instrument.

Szumowski ^72^ randomly assigned 21 young children to an 8-week behavioral intervention that included information on diabetes management plus instruction and practice in the application of behavioral principles and goal setting to reinforce children's regimen adherence. The comparison group received information on diabetes management but no additional instruction. At the 3-month followup there was no significant difference in the number of hypoglycemic episodes experienced by either group, nor was the change from baseline significantly different for either group. The methodological quality of the study was moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

Children with newly diagnosed diabetes. In the CCT by Golden et al. ^19^ 11 families received an integrated diabetes education and psychosocial support program that was delivered in a motel-like setting. The comparison group (n = 8) received the same training 15 months after diagnosis. At 12-month followup, the rate of severe hypoglycemia episodes reported by the intervention group was significantly lower than the comparison group (0.25 per patient vs. 1.1 per patient, respectively [p<0.01]). The methodological quality of the study was low (1/3 on the modified Jadad score).

### Skills Training—Complications

Three studies (1 RCT, ^52^ 2 cohorts ^40,^ ^53^ ) examined the effect of skills training on short-term complications. The studies were conducted in Europe and were published in 2002 ^40,^ ^53^ and 2005. ^52^

### Results

General population of children with diabetes. In the RCT by Nordfeldt et al., ^52^ three groups of patients (n = 332; mean age = 5.3 years) were randomized to receive either videotapes and a brochure with information about practical skills for self-control and treatment (intervention group), a videotape and brochure with general diabetes information, or routine clinical care. Outcomes were assessed at 12 and 24 months following distribution of the education materials. At 12 months there was a reduction in the annual incidence of severe hypoglycemia in the intervention group; there was no significant change for either of the controls groups. This reduction was still present at 24 months; the incidence of severe hypoglycemia in the intervention group decreased from 42 percent to 25 percent (p = 0.023) in the intervention group. The methodological quality of the study was low (1/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

Nordfeldt and Ludvigsson ^53^ evaluated the effect of self-study material on diabetes education aimed at self-management skills and the prevention of hypoglycemia. Over a 3-year period (1997 to 1999) brochures and videos were distributed to the homes of approximately 130 patients and families each year. The mean age of the children was 4.6 years. The mean incidence of severe hypoglycemia with unconsciousness was lower during the 1997-1999 cohort compared to 1994-1996 (pre-intervention); however, the difference was not statistically significant (0.14 to 0.16 events per patient-year vs. 0.17 to 0.22 events per patient-year, respectively). The methodological quality of the study was weak based on the Thomas instrument.

Children with newly diagnosed diabetes. Likitmaskul et al. ^40^ conducted a nonconcurrent cohort study to compare the effect of a multidisciplinary team approach to diabetes education to conventional education that focused on insulin injection and how to control diet. The 28 children who received conventional education were diagnosed with diabetes prior to 1996 and served as an historical comparison group to the 24 children who were diagnosed after 1996. The children who received the multidisciplinary education program had a 4 percent readmission rate for recurrent DKA or hyperglycemia during the first year following diagnosis compared with 18 percent for the comparison group. This difference between groups continued up to 4 years post-diagnosis. The methodological quality of the study was moderate based on the Thomas instrument.

### Diabetes Camp—Complications

Children with poorly controlled diabetes. In an uncontrolled before-and-after study, Karaguzel et al. ^34^ examined the effect of a 1-week diabetes camp that incorporated intensive insulin treatment into a general diabetes program (n = 25). The mean age of the children was 5.0 years. Over the 12-month followup, no severe hypoglycemic episodes were detected. As no baseline data were provided, we cannot determine if this was a change from pre-intervention. The methodological quality of the study was weak based on the Thomas instrument.

### Other Interventions—Complications

General population of children with diabetes. Campaigne et al. ^10^ assessed the effects of physical training on short-term complications. Fourteen adolescents were randomly assigned to either a 12-week exercise program or to a control group that did not modify the usual exercise routine. At the end of the program, there was no change in the occurrence of hypoglycemia in either group. The methodological quality of the study was low (2/5 on the Jadad score; unclear allocation concealment).

### Summary of Results—Complications

Overall, we identified 15 studies that assessed the effectiveness of diabetes education in controlling complications. Of these, 11 (5 RCTs, 3 cohorts, 3 uncontrolled before-and-after) examined the general population of children with type 1 diabetes, 3 studies (1 RCT, 1 CCT, 1 cohort) focused on children with newly diagnosed diabetes, and 1 uncontrolled before-and-after study considered children with poorly controlled diabetes (Table 8). While one of the objectives of this evidence report was to assess the effect of diabetes education on both long- and short-term complications, all of the complications reported in the included studies were short-term. Most studies reported on the incidence of severe hypoglycemia. Six studies reported the incidence of DKA and one study measure chronic hyperglycemia.

Table 8 Summary of results of studies assessing the effect of diabetes education on short-term complications

Author Year | Intervention | Study design Sample size | Quality | Conclusion
General population of children with diabetes
Campaigne ^10^ 1985 | Physical training | RCT 16 | Low | No significant difference between IG and CG in event rate for hypoglycemia at 12 wk.
Grey ^21^ 2000 | Cognitive behavioral therapy | RCT 77 | Moderate | IG reported statistically lower event rates for severe hypoglycemia and DKA at 12 mo.; rates were higher than those reported by the DCCT (i.e., poorer control)
Lawson ^39^ 2000 | General diabetes education | Cohort 28 | Low | No significant difference between IG and CG in event rate for hypoglycemia at 12 mo.
Nordfeldt ^54^ 1999 | Cognitive behavioral therapy | Cohort 139 | Low | Annual event rate for severe hypoglycemia was significantly lower for IG
Nordfeldt ^53^ 2002 | Skills | Cohort 130 | Low | Annual event rate for severe hypoglycemia lower for IG; difference between groups NS
Nordfeldt ^52^ 2005 | Skills | RCT (3 arms) 332 | Low | Event rate for severe hypoglycemia significantly reduced in IG compared with either CG at 12 and 24 mo.
Povlsen ^61^ 2005 | General diabetes education | Before-after 37 | Low | Number of severe hypoglycemic events increased at 6 mo.; difference was NS
Svoren ^71^ 2003 | General diabetes education | RCT (3 arms) 299 | Low | Event rate for severe hypoglycemia significantly reduced in IG compared with either CG at 24 mo.
Szumowski ^72^ 1990 | Cognitive behavioral therapy | RCT 27 | Moderate | No significant change in event rate for severe hypoglycemia for either group at 3 mo.
Verrotti ^75^ 1993 | General diabetes education | Before-after 30 | Moderate | Significant decrease in number of severe hypoglycemic events at 12 mo.
von Sengbusch ^77^ 2006 | General diabetes education | Before-after 107 | Moderate | No significant change in event rate for severe hypoglycemia at 6 mo.
Children with newly diagnosed diabetes
Dougherty ^18^ 1999 | General diabetes education | RCT 63 | Moderate | No significant difference between IG and CG in rate of adverse events (severe hypoglycemia, hyperglycemia and ketosis, DKA, chronic hyperglycemia) at 24 mo.
Golden ^19^ 1985 | Cognitive behavioral therapy | CCT 19 | Low | Event rate for severe hypoglycemia was significantly lower in IG compared with CG at 12 mo.
Likitmaskul ^40^ 2002 | Skills | Cohort 52 | Moderate | IG had significantly fewer readmissions for DKA or hyperglycemia and severe hypoglycemia than CG at 12 mo. and 4 yr. following diagnosis
Children with poorly controlled diabetes
Karaguzel ^34^ 2005 | Diabetes camp | Before-after 25 | Low | No severe hypoglycemic events were detected at 12 mo.

CG = control group; DCCT = Diabetes Control and Complications Trial; IG = intervention group; NS = not significant

General population of children with diabetes. Overall, 11 studies (5 RCTs, ^10,^ ^21,^ ^52,^ ^71,^ ^72^ 3 cohorts, ^39,^ ^53,^ ^54^ 3 uncontrolled before-and-after ^61,^ ^75,^ ^77^ ) assessed the effect of diabetes education on short-term complications among the general population of children with diabetes (Table 8). Three studies examined interventions based on cognitive behavioral therapy, ^21,^ ^54,^ ^72^ five studied general diabetes education interventions, ^39,^ ^61,^ ^71,^ ^75,^ ^77^ 2 assessed skills training ^52,^ ^53^ and one assessed a physical training program. ^10^ Overall the methodological quality was low; only two RCTs (Grey et al., ^21^ Szumowski ^72^ and two uncontrolled before-and-after studies (Verrotti, ^75^ von Sengbusch et al. ^77^ ) were rated as being of moderate quality.

### Results

Grey et al. ^21^ reported that the event rate for severe hypoglycemic events decreased significantly following diabetes education. Verrotti et al. ^75^ also reported that the event rate for severe hypoglycemic events decreased significantly following diabetes education. In contrast Szumowski ^72^ and von Sengbusch et al. ^77^ found that diabetes education had no significant impact on the rate for severe hypoglycemia.

The results of the remaining studies were inconsistent. Three studies ^52,^ ^54,^ ^71^ reported that the event rate for severe hypoglycemic events decreased significantly following diabetes education. Nordfeldt and Ludvigsson ^53^ found that the annual event rate for severe hypoglycemia decreased for both the skills training and comparison groups; however, the difference was not statistically significant. The remaining studies reported that diabetes education had no significant impact on short-term complications. ^10,^ ^39,^ ^61^

Children with newly diagnosed diabetes. Overall three studies (1 RCT, ^18^ 1 CCT, ^19^ 1 cohort ^40^ ) assessed the effect of diabetes education on short-term complications among children with newly diagnosed diabetes (Table 8). One study (Likitmaskul et al. ^40^ ), which was assessed as being of moderate quality, reported that the event rate for severe hypoglycemic events and the number of readmissions for DKA decreased significantly following a skills training intervention. Dougherty et al. ^18^ reported that setting for delivery of general diabetes education (i.e., inpatient vs. ambulatory) had no significant impact on short-term complications. The low quality RCT by Golden et al. ^19^ reported that the event rate for severe hypoglycemic events decreased significantly following a cognitive behavioral therapy intervention.

Children with poorly controlled diabetes. One uncontrolled before-and-after study assessed the effect of a diabetes camp ^34^ on short-term complications among children with poorly controlled diabetes (Table 8). No adverse events were reported by Karaguzel et al. ^34^ during followup.

## Knowledge

Overall 30 studies assessed the effect of diabetes education on knowledge. Of these, 24 examined the general population of children with diabetes, 3 targeted children with newly diagnosed diabetes and 3 considered children with poorly controlled diabetes.

### General Diabetes Education—Knowledge

Description of studies. We identified 13 studies (5 RCTs, ^9,^ ^18,^ ^24,^ ^32,^ ^55^ 2 cohorts, ^66,^ ^69^ 4 uncontrolled before-and-after, ^61,^ ^65,^ ^75,^ ^77^ 2 CCTs, ^42,^ ^45^ ) that assessed the effectiveness of general diabetes education on diabetes-related knowledge. The studies were conducted in the United States, ^9,^ ^32,^ ^45,^ ^66^ Europe, ^24,^ ^42,^ ^61,^ ^75,^ ^77^ Canada, ^18^ India, ^65^ and Australia. ^55,^ ^69^ The median year of publication was 1999 (IQR, 1993 to 2005).

The number of study participants ranged from 30 to 146 (median = 63 [IQR 37 to 107]). The mean age of participants ranged from 10.1 to 15.4 (n = 8 studies). The mean age was less than 12 years in six studies. ^18,^ ^24,^ ^42,^ ^55,^ ^66,^ ^77^ Three studies assessed education interventions delivered to children and their families at the time of diagnosis. ^18,^ ^66,^ ^69^ One study examined children who demonstrated poor metabolic control. ^55^

All of the interventions were aimed at children and their parents or to the entire family. The interventions were delivered in a variety of settings including hospital inpatient units, ^61,^ ^77^ home, ^9^ and an outpatient clinic. ^24^ In seven studies, the setting was mixed (e.g., hospital and home) ^18,^ ^32,^ ^45,^ ^55,^ ^65,^ ^66,^ ^69^ and not reported in two studies. ^42,^ ^75^

There were four studies in which knowledge was not measured beyond completion of the education program. ^9,^ ^24,^ ^32,^ ^55^ In the eight studies that reported post-intervention assessments, ^18,^ ^42,^ ^61,^ ^65,^ ^66,^ ^69,^ ^75,^ ^77^ ranged from 1 to 36 months.

### Results

General population of children with diabetes. Brown et al. ^9^ randomly assigned 59 children and adolescents to a group that played a video game with a focus on nutritional education featuring characters with diabetes or a group that played a pinball video game with no information on diabetes. At the end of the 6-month study period, the intervention group reported more gains in knowledge compared to the control group when assessed using the Diabetes Knowledge Test. The methodological quality of this study was low (1/5 on the Jadad score; unclear concealment of allocation).

In the RCT by Hackett et al., ^24^ three cohorts of families received educational packages that were delivered over 8 months. The content was the same for all groups; one group (cohort 1) received a second reinforcement package for an additional 8 months. The comparison group did not receive the education package. The education program led to an increase in mean knowledge scores, as measured by a multiple choice test, across all cohorts. However, the knowledge was poorly retained by fathers. The methodological quality of this study was low (2/5 on the Jadad score; unclear concealment of allocation).

Howe et al. ^32^ randomly assigned 75 patients to one of three treatment groups: : standard care (routine quarterly clinic visits), standard care plus one education session on basic diabetes management skills, and standard care, the education session plus weekly telephone calls to review management techniques. From results of the KNOW test (46 multiple choice questions) there were no statistically significant differences found in knowledge among the groups. The trial was ended early due to lack of enrolment. The methodological quality of this study was low (2/5 on the Jadad score; unclear concealment of allocation).

In the CCT by Lucey and Wing, ^42^ a general education intervention was delivered to 49 families in the form of two 6-hour group sessions. In the followup period, which ranged from 2 to 44 weeks, the children in the intervention group performed better on a multiple choice questionnaire that tested knowledge than children in the comparison group. The methodological quality of this study was low (0/3 on the modified Jadad score).

Mason ^45^ examined a two to four player board game played by 93 groups of parents and children. The children would collect cards (tools) that could be used for continued control of diabetes. According to a questionnaire, there was no significant difference in knowledge between groups that played the game and those who did not play the game, though both groups significantly improved knowledge from baseline. The methodological quality of this study was low (0/3 on the modified Jadad score).

Povlsen et al. ^61^ assessed the effect of an intervention targeted at 37 families from ethnic minority groups in Denmark. The intervention included adapted educational material and guidelines and re-education that focused on increasing knowledge and self-care. Using the results of a questionnaire, the authors reported a mean increase in knowledge from baseline; however, the differences between families were considerable at the 6-month followup. The methodological quality of this study was weak based on the Thomas instrument.

In the study by Shobhana et al. ^65^ a 1-hour didactic lecture on injection and monitoring skills and individualized diet counseling was delivered to 37 parent and child groups by a multidisciplinary team. A short questionnaire found that immediately post-intervention and at 3 months, there were significant increases in knowledge about diabetes, injections and hypoglycemia. At the 6-month followup, knowledge in all areas increased except with regard to self-monitoring. The methodological quality of this study was weak based on the Thomas instrument.

In an uncontrolled before-and-after study Verrotti et al. ^75^ studied 30 adolescents who attended nine education sessions on general diabetes management. At the 12-month followup, a 20-item multiple choice questionnaire showed that the participants had statistically higher knowledge scores compared to baseline values. The methodological quality of this study was moderate based on the Thomas instrument.

In an uncontrolled before-and-after study, von Sengbusch et al. ^77^ assessed the impact of a mobile diabetes education service in a group of 107 children. There was a statistical improvement in children's knowledge at the 6-month followup according to the results of an age-adapted questionnaire. The methodological quality of this study was moderate based on the Thomas instrument.

Children with newly diagnosed diabetes. Dougherty et al. ^18^ randomly assigned 63 newly diagnosed patients to a 24-month home-based diabetes education program or to traditional hospitalization and outpatient followup. Treatment differences between the groups consisted of duration of initial hospital stay, timing of initial teaching, and the nature and extent of subsequent nursing followup. The Diabetes Knowledge Scale found no significant difference between the groups. The methodological quality of this study was moderate (2/5 on the Jadad score; unclear concealment of allocation; blinding of outcome assessors).

Siminerio et al. ^66^ conducted a prospective cohort study in which a group of 32 newly diagnosed children and their parents and peers received 10 to 12 hours of inpatient or outpatient education sessions over three days. The education addressed aspects of basic diabetes knowledge such as self-management skills, nutrition and exercise. The Test of Diabetes Knowledge found that there was no significant difference in knowledge between the inpatient and outpatient groups. The methodological quality of this study was moderate based on the Thomas instrument.

In the prospective cohort study by Srivivasan et al. ^69^ a group of 61 newly diagnosed patients attended a diabetes day care program (DDCP) at which they received “survival skills” diabetes education. The pre-DDCP cohort comprised 49 patients who were admitted to hospital for 4 to 7 days for a detailed education program. There was no significant difference between the groups' results on the Test of Diabetes Knowledge. The methodological quality of this study was moderate based on the Thomas instrument.

Children with poorly controlled diabetes. Nunn et al. ^55^ randomly assigned 123 patients to receive scheduled telephone calls from a pediatric diabetes educator or standard care (i.e., routine clinic visits but no telephone calls). The intervention was provided for five to eight months. Immediately after the intervention, authors measured knowledge using a modified test of diabetes knowledge and found there to be no significant differences between groups. The methodological quality of this study was high (3/5 on the Jadad score; unclear concealment of allocation).

### Cognitive Behavioral Therapy—Knowledge

Description of studies. Seven studies (3 RCTs, ^22,^ ^31,^ ^72^ 3 CCTs, ^14,^ ^48,^ ^74^ and 1 controlled before-and-after ^20^ ) examined various interventions that used cognitive behavioral therapy techniques to increase knowledge. All but two studies were conducted in the United States; 1 was conducted in Europe ^48^ and 1 was conducted in Australia. ^14^ The median year of publication was 1993 (IQR, 1990 to 1998) and ranged from 1985 to 2001.

The number of participants enrolled in the studies ranged from 14 to 69 (median = 23 [IQR 20 to 32]). The mean age of participants ranged from 6.5 to 14.2 years (5 studies). For 2 studies, the mean age was less than 12 years. ^22,^ ^72^ One study examined education interventions delivered to children who had poor metabolic control. ^14^

In three studies the interventions were delivered to children ^14,^ ^22,^ ^74^ and to parents as well as children in four studies. ^20,^ ^31,^ ^48,^ ^72^ The settings for the interventions were described as an outpatient clinic, ^20,^ ^48,^ ^72^ or home. ^31^ For one study, the setting was mixed (e.g., diabetes center and home). ^14^ Two studies did not report the setting of the intervention. ^22,^ ^74^ All but 2 studies ^20,^ ^31^ conducted post-intervention assessments for knowledge. The median followup period was 12 months and ranged from 3 to 13 months.

### Results

General population of children with diabetes. In the RCT by Gross et al. ^22^ 14 children and parents were randomly assigned to either behavior modification training or to a group that included discussion and role-playing. At 6-month follow up, the intervention group scored significantly higher on the Behavior Modification Test than the control group (p<0.01). The methodological quality of this study was low (2/5 on the Jadad score; unclear allocation concealment).

Szumowski ^72^ randomly assigned 21 young children to an 8-week behavioral intervention that included information on diabetes management plus instruction and practice in the application of behavioral principles and goal setting to reinforce children's regimen adherence. The comparison group received information on diabetes management but no additional instruction. At the 3-month followup parents were assessed using the Knowledge of behavioral principles as applied to children (KBPAC) and the Test of Diabetes Knowledge while children's knowledge was assessed using the Children's Diabetes Quiz. The authors found that there was a significant group by time interaction (p<0.008) for both groups at 3 months. Both children and parents increased their knowledge scores from baseline to 3 months but statistical significance was not reported. The methodological quality of this study was moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

Horan et al. ^31^ conducted an RCT (n = 20) that compared goal setting and problem solving using dynamic computer-assisted teaching modules vs. conventional education using an education booklet. At the end of the 15-week program, assessments of diabetes knowledge were made using multiple choice questions modified from the Test of Diabetes Knowledge. There was no significant difference between the groups with regards to their applied knowledge of diabetes. However more individuals in the intervention group showed improvement in their factual diabetes knowledge than individuals in the control group. The methodological quality of this study was low (2/5 on the Jadad score; unclear allocation concealment).

In a controlled clinical trial, Mendez and Belendez ^48^ delivered 12 sessions to children (n = 37) that provided them with audiovisual and print material and also allowed them to practice their skills. Their parents were taught to reinforce adherence behaviors rather than punish non-compliance. Immediately after the sessions ended, the intervention group had significantly higher results on the Diabetes Information Survey for Children (DISC) (p < 0.001) but at 13 months, the difference between the intervention and control group was not significant (p = 0.087). The methodological quality of this study was low (1/3 on the modified Jadad score).

Thomas-Dobersen et al. ^74^ conducted a controlled clinical trial in which 20 adolescents received 14 sessions over three months addressing various areas of diabetes management such as diet and knowledge of hypoglycemia. Youth Evaluation Scales (YES) found that at 1-year followup, the intervention group showed a statistically significant increase in knowledge compared to the control group (p<0.01). The methodological quality of this study was low (1/3 on the modified Jadad score).

Greco at al. ^20^ conducted an uncontrolled before-and-after study that aimed to implement a structured intervention for integrating peers into diabetes care in a healthy and adaptive manner. There were 23 pairs of patients and peers who were assessed using the Diabetes Education and Support Assessment (DESAT) tool. After the 4-week intervention, the children as well as their peers experienced a significant increase in knowledge compared to baseline (p<0.0001). The methodological quality of this study was moderate based on the Thomas instrument.

Children with poorly controlled diabetes. Couper et al. ^14^ evaluated the effects of monthly home visits by a nurse educator plus weekly telephone calls that focused on goal-setting. Thirty-seven adolescents received routine care plus the regular intervention; 32 received routine clinical care only. At the 6-month followup, both parents and children in the intervention groups, assessed with the Diabetes Knowledge Assessment Scale, had significantly higher knowledge scores than those in the control group (p = 0.001). At 12 months, only the parents maintained this difference between the groups (p = 0.005). The methodological quality of this study was low (1/3 on the modified Jadad score).

### Diabetes Camp—Knowledge

Description of studies. In eight studies (3 RCTs ^58^ – ^60^ , 1 CCT, ^62^ and 4 uncontrolled before-and-after studies ^12,^ ^27,^ ^34,^ ^35^ ) the education intervention was delivered as part of a diabetes camp program. Seven studies were conducted in the United States; one took place in Europe. ^34^ The median year of publication was 1994 and ranged from 1983 to 2005.

The number of participants enrolled ranged from 25 to 237 (median = 76.5 [IQR 61 to 86]). The mean age of participants ranged from 10.0 to 14.83 years. For 1 study, the mean age was less than 12 years. ^35^ One study focused on children who demonstrated poor metabolic control. ^34^

In one study, the intervention was aimed at families ^35^ while the rest of the interventions were targeted only at children. Only three studies conducted assessments immediately after the intervention. ^12,^ ^27,^ ^60^ The remaining five studies conducted post-intervention assessments for knowledge; the median followup period was 8 months and ranged from 2 days to 12 months.

### Results

General population of children with diabetes. In the uncontrolled before-and-after study by Christensen et al. ^12^ the campers attended two sessions on carbohydrate counting and two sessions on food portioning. They used flash cards, practiced reading labels, measuring utensils, used scales with real food and played a card game. The authors used laboratory values to assess the correlations between HbA1c and knowledge and found that the correlation was not statistically significant (p = 0.09). The methodological quality of this study was weak based on the Thomas instrument.

The campers in the controlled before-and-after study by Harkavy et al. ^27^ received informal and formal teaching sessions which covered diabetes etiology/pathology, self-management skills, effects of diabetes on stress and social issues. Immediately after the 2-week camp was over, campers completed a multiple choice questionnaire to assess their knowledge of etiology, pathophysiology and diabetes in general. The authors found that campers 12–13 years and 14–15 years of age showed a significant improvement in knowledge. There was no significant difference found in the 10–11 year olds. The methodological quality of this study was weak based on the Thomas instrument.

In an RCT by Pichert et al., ^60^ 64 campers were randomly assigned to one of two groups: four 45-minute problem-solving sessions where they learned about metabolic management skills, diabetes and exercise guidelines and the social issues surrounding diabetes or the control group that received traditional instruction that did not emphasize problem solving. Immediately following the camp, the campers were asked to complete multiple choice and short answer tests to assess their factual knowledge of and ability to apply diabetes-related exercise guidelines. Repeated measures analysis of variance revealed that problem-solving groups gained more in factual knowledge and the ability to apply it to new problems than did the control group. The methodological quality of this study was low (2/5 on the Jadad score; unclear allocation concealment).

In another RCT by Pichert et al., ^58^ 69 campers were randomized either to the intervention group comprising three 45-minute groups sessions using a problem-solving format devoted to nutrition-related skills and knowledge, or to the control group that received conventional direct instruction. When assessments were performed 2–4 or 5–6 days post-intervention, there was significant improvement in the knowledge in both groups when they were asked to complete a personal meal plan recall, but there was no significant difference between groups. The methodological quality of this study was low (2/5 on the Jadad score; unclear allocation concealment).

In the third RCT by Pichert et al., ^59^ 81 campers were randomized to participate in two 45-minute sessions on sick day management that were taught via a problem-solving format, or to the control group that received conventional direct instruction. Knowledge was assessed using a Sick Day Knowledge Test and a Sick Day Problem Solving Test. At the 8-month followup, there was no significant difference between groups; however, the intervention group was better able to explain why the management guidelines applied to a hypothetical example. The methodological quality of this study was moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

Remley ^62^ conducted a CCT to compare a social cognitive theory-based program with a standard non-theory based camp education program. Eight 1-week camps across the United States were designated deliver either the theory-based intervention or the standard program. At the 3-month followup, there was no significant change in knowledge levels for either group. The attrition rate for both groups was high (40 percent). The methodological quality of this study was low (1/3 on the modified Jadad score).

In an uncontrolled before-and-after study, Kemp et al. ^35^ assessed the effectiveness of diabetes education and carefully monitored blood glucose control among 42 children who attended a 2-week summer camp. One year later, there was a significant improvement in knowledge when comparing pre to post intervention groups (p<0.01 vs. pre-camp). The methodological quality of this study was weak based on the Thomas instrument.

Children with poorly controlled diabetes. In an uncontrolled before-and-after study (n = 25), Karaguzel et al. ^34^ examined the effect of a 1-week diabetes camp that incorporated intensive insulin treatment into a general diabetes program which included dietary education. There was a statistically significant increase in knowledge about diabetes and diabetes nutrition at 6 and 12 month followup. The methodological quality of this study was weak based on the Thomas instrument.

## Skills Training—Knowledge

### Results

General population of children with diabetes. In the uncontrolled before-and-after study by Monaco et al., ^50^ children were divided into two groups, ages 6–8 years and 9–11 years, to receive one session in which they were instructed in the use of injection site charts and injection site bears. The authors found that children in both age groups committed significantly fewer injection site identification errors when using the injection bears compared to using the chart. The methodological quality of this study was moderate based on the Thomas instrument.

In the uncontrolled before-and-after study by Templeton et al., ^73^ adolescents attended one 90-minute session in which they were taught skills that would help them monitor their blood glucose. Immediately after the session they were asked to complete a five item true/false test. While the authors provided data on the percentages of questions correct, they did not comment on the statistical significance of results. The methodological quality of this study was weak based on the Thomas instrument.

### Summary of Results—Knowledge

Overall, we identified 30 studies that assessed the effectiveness of diabetes education in improving knowledge (Table 9). Of these, 24 studies (9 RCTs, 5 CCTs, 10 uncontrolled before-and-after) examined the general population of children with type 1 diabetes, 3 studies (1 RCT, 2 cohorts focused on children with newly diagnosed diabetes, and 3 studies (1 RCT, 1 CCT, 1 uncontrolled before-and-after) considered children with poorly controlled diabetes.

Table 9 Summary of results of studies assessing the effect of diabetes education on knowledge

Author Year | Intervention | Study design Sample size | Quality | Results
General population of children with diabetes
Brown ^9^ 1997 | General diabetes education | RCT 59 | Low | IG significantly improved knowledge scores compared to CG at 6 mo.; difference was NS
Christensen ^12^ 2000 | Diabetes camp | Before-after 68 | Low | No significant change from baseline levels of knowledge
Greco ^20^ 2001 | Cognitive behavioral therapy | Before-after 23 | Moderate | Adolescents and their peers achieved significant increases in knowledge
Gross ^22^ 1985 | Cognitive behavioral therapy | RCT 14 | Low | IG had significantly higher knowledge scores compared to CG at 6 mo.
Hackett ^24^ 1989 | General diabetes education | RCT (4 arms) 119 | Low | Knowledge scores increased significantly for children, mothers and fathers in IG; gains not sustained by fathers over 8 mo.
Harkavy ^27^ 1983 | Diabetes camp | Before-after 93 | Low | Significant improvement in knowledge for 12–13 and 14–15-yr. olds; no significant difference for 10–11-yr. olds
Horan ^31^ 1990 | Cognitive behavioral therapy | RCT 20 | Low | No significant difference between groups post-intervention
Howe ^32^ 2005 | General diabetes education | RCT (3 arms) 89 | Low | No significant differences among groups at 6 mo.
Kemp ^35^ 1986 | Diabetes camp | Before-after 42 | Low | Knowledge scores improved significantly from baseline to post-intervention
Lucey ^42^ 1985 | General diabetes education | CCT 49 | Low | IG performed better on general information questions than CG
Mason ^45^ 1986 | Cognitive behavioral therapy | CCT 93 | Low | Both groups significantly improved knowledge scores; difference was NS
Mendez ^48^ 1997 | Cognitive behavioral therapy | CCT 37 | Low | IG significantly higher than CG at post-intervention; difference was NS at 13 mo.
Monaco ^50^ 1996 | Skills training | Before-after 58 | Moderate | Both groups significantly improved knowledge scores from baseline; difference was NS
Pichert ^60^ 1993 | Diabetes camp | RCT 146 | Low | IG knowledge improved significantly more than CG for diabetes-related exercise guidelines and ability to apply knowledge
Pichert ^58^ 1994a | Diabetes camp | RCT 83 | Low | Both groups improved significantly in recall of nutritional meal plans, knowledge of food groups, exchange equivalents, portions; difference was NS at post-camp
Pichert ^59^ 1994b | Diabetes camp | RCT 84 | Moderate | No significant difference between groups at 8 mo.
Povlsen ^61^ 2005 | General diabetes education | Before-after 37 | Low | Knowledge increased from baseline; difference was NS
Remley ^62^ 1999 | Diabetes camp | CCT 237 | Low | No significant increase in knowledge levels for either group
Shobhana ^65^ 1997 | General diabetes education | Before-after 37 | Low | Significant increase in knowledge at 6 mo.
Szumowski ^72^ 1990 | Cognitive behavioral therapy | RCT 27 | Moderate | Parents in IG increased knowledge of behavioral principles compared to CG at 3 mo. Parents in both groups increased knowledge of diabetes at 3 mo.; difference was NS Children in both groups increased knowledge of diabetes at 3 mo.; difference was NS
Templeton ^73^ 1988 | Skills training | Before-after 30 | Low | Knowledge increased from baseline; statistical significance NR
Thomas-Dobersen ^74^ 1993 | Cognitive behavioral therapy | CCT 20 | Low | IG had significant increase in knowledge compared to CG at 15 mo.
Verrotti ^75^ 1993 | General diabetes education | Before-after 30 | Moderate | Significantly higher knowledge scores at 12 mo.
von Sengbusch ^77^ 2006 | General diabetes education | Before-after 107 | Moderate | Significant improvement in knowledge scores compared to baseline
Children with newly diagnosed diabetes
Dougherty ^18^ 1999 | General diabetes education | RCT 63 | Moderate | No significant difference between groups at 36 mo.
Siminerio ^66^ 1999 | General diabetes education | Cohort 32 | Moderate | No significant difference between groups at 1 mo.
Srinivasan ^69^ 2004 | General diabetes education | Cohort 110 | Moderate | No significant difference between groups at 12 mo.
Children with poorly controlled diabetes
Couper ^14^ 1999 | Cognitive behavioral therapy | CCT 69 | Low | IG children had significantly higher knowledge scores than CG at 6 mo.; difference was NS at 12 mo. IG parents had significantly higher knowledge scores than CG at 6 and 12 mo.
Karaguzel ^34^ 2005 | Diabetes camp | Before-after 25 | Low | Significant increase in knowledge scores at 12 mo.
Nunn ^55^ 2006 | General diabetes education | RCT 146 | High | No significant difference in knowledge scores between groups

CG = control group; IG = intervention group; NR = not reported; NS = not significant

General population of children with diabetes. Twenty-four studies (9 RCTs, ^9,^ ^22,^ ^24,^ ^31,^ ^32,^ ^58^ – ^60,^ ^72^ 5 CCTs, ^42,^ ^45,^ ^48,^ ^62,^ ^74^ 10 uncontrolled before-and-after ^12,^ ^20,^ ^27,^ ^35,^ ^50,^ ^61,^ ^65,^ ^73,^ ^75,^ ^77^ ) assessed the effectiveness of diabetes education in improving diabetes-related knowledge among the general population of children with diabetes. Eight studies assessed general diabetes education, ^9,^ ^24,^ ^32,^ ^42,^ ^45,^ ^61,^ ^65,^ ^77^ six examined interventions that used cognitive behavioral therapy techniques, ^20,^ ^22,^ ^31,^ ^48,^ ^72,^ ^74^ 7 assessed interventions delivered at diabetes camps, ^12,^ ^27,^ ^35,^ ^58^ – ^60,^ ^62^ and two assessed skills training. ^50,^ ^73^ Overall the methodological quality of the studies was low; only 2 RCTs ^59,^ ^72^ and 34 uncontrolled before-and-after studies ^20,^ ^50,^ ^75,^ ^77^ were rated as being of moderate quality.

Results. The results of the 5 moderate quality studies were inconsistent (Table 9). Sumowski ^72^ reported increased knowledge levels in both the intervention and control groups, but the difference between groups was not statistically significant. Three uncontrolled before-and-after studies (Greco et al., ^20^ Verrotti et al., ^75^ and von Sengbusch et al. ^77^ ) reported gains in knowledge following a cognitive behavior therapy and general diabetes intervention, respectively. Monaco et al. ^50^ reported increases in knowledge levels, but the difference was not statistically significant. In the RCT by Pichert et al. ^59^ knowledge of nutrition and meal planning improved for both intervention and control groups, but the difference was not statistically significant.

The results of the remaining studies were also mixed. Two RCTs, ^22,^ ^60^ one CCT ^74^ and two uncontrolled before-and-after studies ^35,^ ^65^ reported statistically significant increases in diabetes-related knowledge following the education interventions. Two studies reported that their interventions were effective in subgroups of the study population. ^24,^ ^27^ Three trials and three uncontrolled before-and-after studies reported knowledge gains but the differences were not statistically significant ^9,^ ^42,^ ^58,^ ^61,^ ^73^ or were not retained over the longer term. ^48^ In the remaining studies, the education interventions did not have significant effect on knowledge outcomes. ^12,^ ^31,^ ^32,^ ^45,^ ^62^

Children with newly diagnosed diabetes. Three moderate quality studies (1 RCT by Dougherty et al., ^18^ 2 cohorts by Siminerio et al. ^66^ and Srinivasan et al. ^69^ ) compared groups of children with newly diagnosed diabetes that received general diabetes education programs delivered in an ambulatory setting (e.g., home, outpatient clinic) vs. a hospital inpatient setting (Table 9). In all three studies, the knowledge levels increased for both intervention and comparisons groups; however, the differences were not statistically significant. The setting of the education program does not appear to have an effect on knowledge outcomes.

Children with poorly controlled diabetes. The large high-quality RCT by Nunn et al, ^55^ reported no significant differences in knowledge between the intervention group that received general diabetes education plus telephone followup and the control group that received diabetes education with no telephone followup (Table 9). The remaining studies that targeted patients with poorly controlled diabetes were of low quality. One uncontrolled before-and-after reported significant increases in knowledge following a diabetes camp; ^34^ one CCT reported significantly higher knowledge levels over the short-term, but these gains were not sustained over the long-term. ^14^

## Skills

Overall, there were nine studies were assessed the effect of diabetes education on skills. Of these, all studies evaluated the general population of children with diabetes.

### Cognitive Behavioral Therapy—Skills

#### Results

General population of children with diabetes. Anderson et al. ^6^ randomized 70 adolescents and parents to a group that received standard care (routine clinic visits) or a group that received standard care plus a problem solving intervention that focused on self-monitoring of blood glucose (SMBG). At the 18-month followup the authors found no significant difference between groups in their use of SMBG to modify their diet, insulin or daily exercise. The methodological quality of the study was low (2/5 on the Jadad score; unclear allocation concealment).

In the CCT by Mendez et al., ^48^ 37 adolescents and parents were divided into experimental and control groups. The intervention group underwent 12 sessions. The sessions delivered to the adolescents included review, new content (audiovisual and printed material), skill practice and homework assignment. Parents attended two sessions emphasizing reinforcement and adherence behaviors rather than punishing noncompliance. There was no description of the control group. At the 13-month followup the authors found that the intervention group had significantly higher posttest scores than the control group on blood glucose testing skills. The methodological quality of the study was low (1/3 on the modified Jadad score).

### Diabetes Camp—Skills

Description of studies. We identified seven studies (2 RCTs, ^58,^ ^81^ 1 CCT, ^62^ 4 uncontrolled before-and-after ^12,^ ^27,^ ^37,^ ^78^ ) that assessed the effects of diabetes camp on the development of diabetes-related skills. Studies were conducted in the United States, ^12,^ ^27,^ ^37,^ ^58,^ ^62^ Canada, ^81^ and Europe. ^78^ The median year of publication was 1996 and ranged from 1983 to 2001.

The number of participants in the studies ranged from 41 to 237 (median = 83, [IQR 63 to 112]). The mean age of participants ranged from 8.4 years to 14.53 years (n = 3 studies). ^27,^ ^62,^ ^78^ For one study the mean age of participants was less than 12 years. ^78^ One study focused on children who demonstrated poor metabolic control. ^81^

Three studies reported immediate post-intervention assessment. ^12,^ ^27,^ ^81^ The remaining followup times were 2 to 6 days post-intervention, ^58^ 2 months, ^78^ and 3 months. ^37,^ ^62^

#### Results

General population of children with diabetes. In the RCT by Pichert et al. ^58^ 83 children were randomized into two groups, where the intervention group received three 45-minute sessions devoted to nutrition-related skills and knowledge through the use of written material and video. The sessions were based on anchored instruction. The control group also received three 45-minute sessions using flash cards to learn food group/exchange equivalents and meal planning. On an observed test to see if campers could select an appropriate meal, both groups showed improvement, but there was no significant difference. In a challenge to choose meals for an overnight trip no significant difference was observed between groups, although both showed improvement. The methodological quality of the study was low (2/5 on the Jadad score; unclear allocation concealment).

Remley ^62^ conducted a CCT to compare a social cognitive theory-based program with a standard non-theory based camp education program. The curriculum included assertive communication training, group discussion, role-playing and nutrition education. Eight 1-week camps across the United States delivered either the intervention or control program. The attrition rate, at the 3-month followup, for both groups was high (40 percent). Participants in the theory-based program decreased slightly in the self-management skills, meal planning self-efficacy, from pre- to post-camp measurements. Control group scores increased slightly. The methodological quality of the study was low (1/3 on the modified Jadad score).

In an uncontrolled before-and-after study, Christensen et al. ^12^ observed 68 children attending a 2-week camp in the United States. Children were grouped by age so that each class could be tailored to developmental needs. Classes used flash cards, a card game, practiced reading labels, and used measuring utensils and scales with real food. Topics included carbohydrate counting, reading labels, and portion sizes and how to adjust for activity level. Immediate followup demonstrated a 24 percent increase in the campers' abilities to write out meal plans and a 19 percent increase in the ability to accurately describe a meal plan. The change in ability to select appropriate portion sizes was not statistically significant. There was a significant correlation with correctly measuring carbohydrates and participant HbA1c. The methodological quality of the study was low based on the Thomas instrument.

In the uncontrolled before-and-after study by Harkavy et al., ^27^ 93 children participated in a 2-week camp held in the United States. During the camp there were formal and information sessions, but most teaching was completed informally. Topics included general diabetes knowledge, daily management, diet, exercise, hypoglycemia, the effects of illness/stress, and teen social issues. Two skills were assessed: urine testing and insulin injection. At the end of camp, all campers demonstrated improved urine test skills, although girls performed urine tests more accurately than boys. Improvement was significant for 12- to 13- and 14- to 15-year-olds but not significant for 10- to 11-year-olds. In regard to insulin injection skills, girls performed more accurately than boys and improved their accuracy during the camp; boys demonstrated no significant change. The methodological quality of the study was low based on the Thomas instrument.

Koontz ^37^ conducted an uncontrolled before-and-after study that involved 112 children at a 1-week camp in the United States. Education sought to increase self-management skills by teaching insulin administration, relationships between diet, exercise and insulin, meal and snack planning, measuring food portions, and how to identify and treat insulin reactions. The camp also aimed to enhance emotional adjustment, improve self-esteem, and develop positive attitudes toward the outdoors. Followup took place 3 months post-intervention. There was no significant difference in self-management scores from pre-to post-camp. The methodological quality of the study was moderate based on the Thomas instrument.

One study, a RCT ^81^ assessed the effects of a diabetes camp on the development of diabetes-related skills among children with poorly controlled diabetes. This study took place in Canada and involved 41 children. Participants were randomized to either the control group, or the intervention group, where campers received one to two individualized sessions and participated in small group discussion on self-testing. Children in the control group received no specialized education. Immediate followup revealed no significant differences between groups on absolute systematic errors in SMBG comparing baseline to post-intervention. The methodological quality of the study was low (2/5 on the Jadad score; unclear allocation concealment).

The last uncontrolled before-and-after study was conducted in the United Kingdom by Vyas et al. ^78^ and involved 63 children separated into two camps. Children 5 to 7 years of age attended a camp for 10 days and children 9 to 14 years of age attended a different camp for 14 days. Activities at each camp were similar and children learned self-management and problem solving skills through daily activities. Additional opportunities for learning occurred through small informal discussions. Significant increases were seen in the ability of campers to self-test at 3 months post-holiday compared to before camp. The ability to independently self-inject also increased significantly at the post-holiday assessment. The methodological quality of the study was low based on the Thomas instrument.

### Summary of Results—Skills

General population of children with diabetes. Overall, nine studies (3 RCTs, ^6,^ ^58,^ ^81^ 2 CCTs, ^48,^ ^62^ 4 uncontrolled before-and-after ^12,^ ^27,^ ^37,^ ^78^ ) assessed the effects of diabetes education on the development of diabetes-related skills (Table 10). The interventions that were assessed were cognitive behavioral therapy ^6,^ ^48^ and diabetes camps. ^12,^ ^27,^ ^37,^ ^58,^ ^62,^ ^78^ In general, the methodological quality of the studies was low; one study was rated as moderate quality (Koontz ^37^ ).

Table 10 Summary of results of studies assessing the effect of diabetes education on skills

Author Year | Intervention | Study design Sample size | Quality | Conclusion
General population of children with diabetes
Anderson ^6^ 1989 | Cognitive behavioral therapy | RCT 70 | Low | No significant difference in self-monitoring skills
Christensen ^12^ 2000 | Diabetes camp | Before-after 68 | Low | Create meal plans—24% increase in pre—post values; Describe meal plan—19% increase in pre—post values; Portion sizes—no significant difference; Carbohydrate measuring—significant improvement
Harkavy ^27^ 1983 | Diabetes camp | Before-after 93 | Low | Urine testing—both sexes improved significantly, but girls performed more accurately; Significant improvement for 12–13 and 14–15-yr. olds, no significant difference in 10–11-yr. olds; Insulin injection—girls performed more accurately and improved their accuracy during camp
Koontz ^37^ 2001 | Diabetes camp | Before-after 112 | Moderate | No significant difference in self-management skills
Mendez ^48^ 1997 | Cognitive behavioral therapy | CCT 37 | Low | IG had significantly improved self-management skills than CG at 13 mo.
Pichert ^58^ 1994a | Diabetes camp | RCT 83 | Low | Behavioral measures—no significant difference between groups Meal selection—no significant difference between groups
Remley ^62^ 1999 | Diabetes camp | RCT 237 | Low | IG self-management skills decreased slightly, CG increased slightly; difference was NS
Vyas ^78^ 1988 | Diabetes camp | Before-after 63 | Low | Self testing—significant increase in ability; Independent self-injection—significant increase in ability
Wolanski ^81^ 1996 | Diabetes camp | RCT 41 | Low | SMBG—no significant difference in absolute or random errors

CG = control group; IG = intervention group; NS = not significant; SMBG = self-monitoring blood glucose

Results. The uncontrolled before-and-after study by Koontz ^37^ examined a range of self-management skills aimed at improving glycemic control. There were no significant differences in self-management scores at the 3-month followup.The results of the remaining low quality studies were inconsistent. The outcomes of three studies were associated with monitoring blood glucose. One study ^6^ found no significant difference between intervention and control groups on the use of SMBG to modify diet, insulin or daily exercise, whereas, the other ^48^ found improved posttest scores on blood glucose testing in the intervention group compared to the control group. The third ^81^ found no significant difference between intervention and control groups in regard to performing SMBG (Table 10).

Three studies examined nutrition and diet related skills, all of which were tested in a diabetes camp setting. Two studies found no improvement in ability to choose meals or pack for an over-night trip ^58^ or in meal-planning self-efficacy. ^62^ Conversely, another study ^12^ noted increases in the ability to write-out and describe meal plans, but no change in the ability to select appropriate meal sizes.

Skills such as urine and blood testing and insulin injection were assessed in two studies in a camp setting. Both studies found improvements in these skills. ^27,^ ^78^

## Self-Management/Adherence

We identified 21 studies that assessed the effect of education on self-management and regimen adherence. Of these, 14 studies targeted the general population of children with diabetes, 2 examined children with newly diagnosed diabetes, and 5 looked a children with poorly controlled diabetes.

### General Diabetes Education—Self-Management/Adherence

Description of studies. We identified seven studies (5 RCTs, ^9,^ ^15,^ ^18,^ ^24,^ ^32^ 1 cohort, ^66^ 1 uncontrolled before-and-after ^20^ ) that assessed the effect of general diabetes education programs on self-management and adherence outcomes. Studies were conducted in the United States, ^9,^ ^20,^ ^32^ Canada, ^15,^ ^18^ and Europe. ^24^ The median year of publication was 1998 and ranged from 1989 to 2005.

The number of participants in the studies ranged from 23 to 119 (median = 48 [IQR 32 to 76]). The mean age of participants ranged from 9.8 to 14.7 years (n = 7 studies). Two studies included participants where the mean age was less than 12 years. ^18,^ ^24^ Two studies focused on children and their families with newly diagnosed diabetes ^18,^ ^66^ and one targeted children with poor metabolic control. ^15^

Most interventions were delivered to both children and their parents or the family; in one study the intervention was delivered to children only. ^9^ The settings for interventions were described as home, ^9^ clinic, ^24^ or mixed (e.g., hospital and home). ^18,^ ^32,^ ^66^ The setting was not clearly described in two studies. ^15,^ ^20^ Three studies reported post-intervention followup assessments ranging from 1 to 36 months. ^15,^ ^18,^ ^66^ The median follow-up period was 13 months. The remaining studies did not report outcomes beyond the end of the education program. ^9,^ ^24,^ ^32,^ ^83^

#### Results

General population of children with diabetes. Brown et al. ^9^ randomly assigned 59 children and adolescents to a group that played a video game featuring characters that had diabetes, who manage their diabetes by monitoring blood glucose, taking insulin injections and choosing foods, or a group that played a pinball video game with no information about diabetes. Parents rated their child's motivation to manage their diabetes in terms of behaviors such as testing blood sugar, taking insulin, cooperating with parents and doctor, and eating a good diet. At the end of the 6-month study period, the treatment group demonstrated significantly more gains in self-care behavior than the control group (change score 0.28±0.86 vs. -0.38±0.79, respectively [p = 0.003]). The methodological quality of this study was rated as low (1/5 on the Jadad score; unclear allocation concealment).

In the RCT by Hackett et al., ^24^ three cohorts of families received educational packages delivered over 8 months that included information on diabetes, diet and concentration of HbA1c. The content was the same for all groups; one group (cohort 1) received a second reinforcement package for an additional 8 months. The comparison group did not receive the education package. Outcomes included self-reported (by diary) fat, carbohydrate, and fiber intake. Children whose families had attended all educational sessions reported lower fat and higher carbohydrate and fiber intake than those who did not attend, however, this effect was not statistically significant. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Howe et al. ^32^ randomly assigned 75 patients to one of three treatment groups: : standard care (routine quarterly clinic visits), standard care plus one education session on basic diabetes management skills (SC+ED), and standard care plus the education session plus weekly telephone calls to review management techniques (SC+TCM). The authors assessed child and family behaviors related to diabetes safety and control using the Adherence Evaluation scale. At the 6-month followup, adherence improved significantly in the SC+TCM group compared to the standard care group (24 percent vs. 2 percent respectively [p = 0.0003]). Furthermore, children in the SC+TCM group were better able to assume age-appropriate behaviors related to diabetes management, and parents were better able to provide age-appropriate supervision. All outcomes were physician assessed using the TEAM checklist. TEAM scores in the education and telephone case management group improved by 24 percent over a 6-month period, while the standard care group reduced their score by 5.4 percent (p = 0.003). The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

The uncontrolled before-and-after study by Greco et al. ^20^ delivered the intervention in 2-hour sessions over 4 weeks to groups of three to six diabetes patient-peer pairs. The intervention consisted of homework review on etiology, physiology and treatment of diabetes, reflective listening skills, problem solving related to diabetes, stress management, games or exercises to practice concepts and homework assignments. Regimen adherence was measured using the Self-Care Inventory. There was no significant change in adherence scores between baseline and post-intervention. The methodological quality of this study was rated as moderate using the Thomas instrument.

Children with newly diagnosed diabetes. Dougherty et al. ^18^ randomly assigned 63 newly diagnosed patients to a 24-month home-based diabetes education program or to traditional hospitalization and outpatient followup. Treatment differences between the groups consisted of duration of initial hospital stay, timing of initial teaching, and the nature and extent of subsequent nursing followup. The authors assessed adherence using the Diabetes Regimen Adherence Questionnaire There were no significant differences in adherence scores between the groups at any time during the 2-year followup. Adherence was high in both the hospital- and home-based groups: 85.5 percent vs. 82.5 percent, respectively at 1-month and declining slightly to 74.1 percent vs. 73.9 percent at 24-months post-intervention. The methodological quality of this study was rated as moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

Siminerio ^66^ compared a 3 to 5 day education program delivered on an inpatient vs. outpatient basis. Patients were divided into two cohorts of 16 patients each. The education program included basic education on diabetes, complications, self-management skills, and nutrition and exercise. The authors assessed food regulation, exercise, blood glucose regulation and emergency precautions. At 1-month followup, both groups had a high level of adherence for food regulation and exercise; there were no statistically significant differences between the groups. However, the inpatient group scored significantly higher in blood glucose monitoring than the outpatient group (4.93 vs. 4.47, respectively [p < 0.01]). The outpatient group scored higher in adhering to emergency precautions (4.71 vs. 4.44, respectively [p < 0.001]). The methodological quality of this study was rated as moderate using the Thomas instrument.

Children with poorly controlled diabetes. In the RCT by Coupland ^15^ adolescents and their families participated in a family-based intervention to improve adherence (n = 15); the comparison group (n = 14) comprised adolescents who were taught stress management techniques. Adherence behaviors consisted of self-reported regularity of insulin injections, blood glucose testing timeliness and frequency, and diet and exercise levels. At the 3- and 6-month followup, adolescents in the intervention group had a significant increase in mean frequency of daily blood glucose testing compared to the control group; they also had significantly greater adherence for timing of blood glucose testing. Adolescents in the control group showed decreased adherence to correct timing of insulin injections. There was no significant difference between groups in adherence to diet or daily exercise levels. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

### Cognitive Behavioral Therapy—Self-Management/Adherence

Description of studies. We identified eight studies (7 RCTs, ^8,^ ^16,^ ^31,^ ^47,^ ^72,^ ^80^ 1 CCT ^48^ ) that assessed the effect of interventions using cognitive behavioral therapy techniques on self-management and adherence outcomes. One study was conducted in Europe; ^48^ the remaining studies were conducted in the United States. The median year of publication was 1991 and ranged from 1985 to 1999.

The number of participants in the studies ranged from 13 to 66 (median = 24 [IQR 17 to 29]). The mean age of participants ranged from 6.4 to 15.4 years (n = 6 studies). Four studies included participants whose mean age was less than 12 years. ^22,^ ^47,^ ^72,^ ^80^ Two studies examined interventions delivered to children with poor metabolic control. ^8,^ ^16^

Interventions were delivered to children ^8,^ ^31^ or to parents and children or the entire family. ^16,^ ^22,^ ^47,^ ^72,^ ^80^ The settings for interventions were described as an outpatient clinic, ^8,^ ^16,^ ^72,^ ^80^ home, ^31^ diabetes center, ^47^ or mixed. ^48^ The setting was not clearly described in one study. ^22^ All but one study ^31^ reported post-intervention followup assessments ranging from 6 weeks to 6 months (median = 3 months).

#### Results

General population of children with diabetes. In the RCT by Gross et al. ^22^ 14 children and parents were randomly assigned to either behavior modification training or to a group that included discussion and role-playing. The authors assessed adherence using a subjective rating scale in which parent rated child behavior on a 4-point scale. At 6 months parents from the intervention group rated children as improved on all measures while control group parents gave decreased ratings. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Horan et al. ^31^ conducted an RCT (n = 20) that compared goal setting and problem solving using dynamic computer-assisted teaching modules that focused on self-management training versus conventional education using an education booklet. At the end of the 15-week study, participants were asked if they, rather than parents or doctor, were more active in controlling their diabetes. Sixty percent of intervention group vs. 20 percent of the control group reported they were more active at the end of the study. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

In the study by McNabb et al. ^47^ 24 children were randomly assigned to either a 6-week self-management education program or to receive standard care (routine clinic visits). Parents were surveyed using the Children's Diabetes Inventory to report the frequency with which self-care behaviors were practiced in the home and the degree of responsibility assumed by the child. At the end of the program, children in the intervention group were assuming significantly more responsibility for self-care than children in the control group (2.9±0.4 vs. 2.3± 0.6, respectively [p < 0.01]). There was no difference between the groups in frequency of self-care behaviors (4.5±0.4 vs. 4.2±0.6 for the control group). This supported the hypothesis that children would become more responsible for self-care while continuing to maintain self-care frequency. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

The CCT by Mendez and Belendez ^48^ used an intervention comprising 12 sessions of content delivery, skill practice and homework assignment, and involved parents for two of the sessions. The emphasis was on reinforcement of adherence behaviors rather than punishing noncompliance. The intervention delivered to the control group care was not described. The authors reported that frequency of self-monitoring of blood glucose improved in the intervention group immediately following the intervention (18.42±10.92 vs. 21.28±9.78 compared to 18.57±11.78 vs. 18.69±11.67 for the control group, p = 0.016). However, at 13 months post-intervention, the frequency dropped to baseline levels. The authors also assessed self-reported physical activity and nutritional management; they found that the program did not have any effect on dietary or exercise adherence. The methodological quality of this study was rated as low (1/3 on the modified Jadad score).

Szumowski ^72^ randomly assigned 21 young children to an 8-week behavioral intervention that included information on diabetes management plus instruction and practice in the application of behavioral principles and goal setting to reinforce children's regimen adherence. The comparison group received information on diabetes management but no additional instruction. At the 3-month followup, the intervention group reported increased cooperation with diabetes tasks compared to the control group; however, the change from baseline was not statistically significant (2.4±0.8 vs. 2.1±1.0 and 2.4±1.4 vs. 2.9±0.8, respectively [p = 0.09]). There was no significant change for either group in daily average exercise and diet exchange errors (daily average proportion of total recommended exchanges which were added or deleted). There was no significant change in the percent carbohydrate and fat consumed by either group; however, there was a significant decrease in consumption of concentrated sweets in the intervention group vs. no change for the control group. The methodological quality of this study was rated as moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

In the RCT by Webb, ^80^ 45 families were assigned to a group that received intensive collaborative goal setting training or a group that used a goal setting worksheet with guidance from a therapist. The author used the Goal Attainment Scaling to measure goal attainment in self-care behavior areas such as insulin administration, SMBG, food intake and physical activity. At the 3-month followup, both groups reported significant gains in goal attainment for all four areas. The gains reported by the intervention group were significantly greater than those of the control group. The methodological quality of this study was rated as low (1/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

Children with poorly controlled diabetes. In the RCT (n = 19) by Boardway et al., ^8^ a 3-month stress management training program for adolescents was compared to standard outpatient care. The authors used a 24-hour recall interview to assess regimen adherence. At the end of the intervention, there were no significant changes in regimen adherence for either group. The methodological quality of this study was rated as low (1/5 on the Jadad score; unclear allocation concealment).

Delamater et al. ^16^ randomized 13 adolescents to receive a 2-month family-based behavior therapy program with training in parent-teen communication, problem solving and goal setting, with focus on adjusting meals and insulin in response to self-monitoring of blood glucose- or to standard outpatient care. Regimen adherence was measured through using the Diabetes Management Questionnaire. At the 4-month followup, patients in both groups improved their adherence ratings; however, there was no significant difference between the groups. Parent ratings of adherence did not show any significant effects for either group. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

### Family Therapy—Self-Management/Adherence

General population of children with diabetes. Laffel et al. ^38^ randomly assigned 105 families to a family-focused teamwork intervention (TW) or to standard care (i.e., routine multidisciplinary clinical care). Measures of parental involvement in management tasks were reported by both parents and children. At the end of the 12-month intervention the TW families maintained or increased family involvement significantly more than families in the control group (30 percent vs. 14 percent, respectively [p = 0.05]). The methodological quality of this study was low (2/5 on the Jadad score; unclear concealment of allocation).

Wysocki et al. ^82^ randomized 104 families to one of three groups: standard care plus behavioral family systems therapy (BFST), standard care plus family education and support (ES), and standard care (physician directed clinical care). Treatment adherence was assessed using the Diabetes Self-Management Profile (DSMP). At all followup periods up to 12-months post-intervention, the BFST group had significantly better DSMP scores than the standard care group. There were no significant differences between the BFST and the ES groups or between the ES and standard care groups at any followup point. A significantly higher percentage of BFST group members attained moderate or greater improvement (i.e., an increase in score of ≥5 points on the DSMP) in treatment adherence compared with either of the comparison groups. Changes in treatment adherence correlated significantly with change in HbA1c at each time point. The methodological quality of this study was low (2/5 on the Jadad score; unclear concealment of allocation).

Children with poorly controlled diabetes. Wysocki et al. ^83^ randomly assigned 119 children to 1 of 3 groups: standard care (physician directed clinical therapy), education and support (standard care plus 10 sessions of a diabetes support group), and BFST (standard care plus family problem-solving and communication training and individualized treatment plan). The authors measured adherence with the Self-Care Inventory (SCI). At the end of the 3-month intervention, there were no significant differences in regimen adherence among the three groups. The methodological quality of this study was high (3/5 on the Jadad score; adequate concealment of allocation).

In an uncontrolled before-and-after study, Harris et al. ^28^ reported 6-month followup data for 18 adolescents and their families who enrolled in a BFST program. The authors used two self-report measures to assess adherence: the SCI (measuring treatment adherence over 2 weeks) and the Diabetes Mismanagement Questionnaire. There was a small improvement in reports from fathers on the SCI at immediate post-intervention. However, there were no significant differences in adherence reports from adolescent, mother or father at the 6-month followup. The methodological quality of this study was low based on the Thomas instrument.

### Diabetes Camp—Self-Management/Adherence

General population of children with diabetes. Remley ^62^ conducted a CCT to compare a social cognitive theory-based program that focused on assertive communication and nutrition education with a standard non-theory based camp education program. Eight 1-week camps across the United States were designated to deliver either the theory-based intervention or the standard program. At the 3-month followup there were no significant differences in self-reported self-management skills between the groups. The methodological quality of this study was low (1/3 on the modified Jadad score).

Zorumski ^84^ investigated the effects of self-care training for 49 children. All children received basic self-care training from their physicians; 27 also attended a 1-week day camp that provided additional self-care instruction. At the 4-month followup both groups reported an increase in the number of self-care behaviors that they practiced; however, there was no statistically significant difference between groups. The methodological quality of this study was low (0/3 on the modified Jadad score).

### Summary of Results—Self-management/Adherence

Overall, we identify 21 studies that assessed self-management or regimen adherence. Of these, 15 studies examined the general population of children with type 1 diabetes, five examined children with poorly controlled diabetes, and one focused on children with newly diagnosed diabetes(Table 11). We were unable to pool the results of any of the studies due to differences across studies in terms of population, interventions, comparison groups, duration of intervention and followup timepoints.

Table 11 Summary of results of studies assessing the effect of diabetes education on self management/regimen adherence

Author Year | Intervention | Study design Sample size | Quality | Conclusion
General population of children with diabetes
Brown ^9^ 1997 | General diabetes education | RCT 59 | Low | Self-Management—IG had significant gains in self-care compared to CG at 6 mo.
Greco ^20^ 2001 | General diabetes education | Before-after 23 | Moderate | Adherence—No significant change for either group at 4 wk.
Gross ^22^ 1985 | Cognitive behavioral therapy | RCT 14 | Low | Adherence—IG showed an increase in compliance compared to CG at 6 mo.
Hackett ^24^ 1989 | General diabetes education | RCT (4 arms) 119 | Low | Self-Management—No significant difference for either group in nutritional management
Horan ^31^ 1990 | Cognitive behavioral therapy | RCT 20 | Low | Self-Management—IG showed greater behavioral change compared to CG at 15 wk.
Howe ^32^ 2005 | General diabetes education | RCT (3 arms) 89 | Low | Self-Management—Significant group × time interaction; significant increase in ED+ group compared to CG for roles/responsibilities
Laffel ^38^ 2003 | Family therapy | RCT 105 | Low | Self-Management—IG had significantly more involvement in roles/responsibilities than CG at 12 mo.
McNabb ^47^ 1994 | Cognitive behavioral therapy | RCT 24 | Low | Self-Management—No significant difference between groups after 12 wk.
Mendez ^48^ 1997 | General diabetes education | CCT 37 | Low | Self-Management—IG significantly higher skills than CG at posttest; IG significantly higher at nutritional management and physical activity than CG at posttest (loses significance at 13 mo.)
Remley ^62^ 1999 | Diabetes camp | CCT 237 | Low | Self-Management—No significant difference between groups at 3 mo.
Szumowski ^72^ 1990 | Cognitive behavioral therapy | RCT 27 | Low | Self-Management—Significant interaction comparing baseline to 3 mo.; Roles/responsibilities—No significant change in either group at 3 mo.; Physical activity or nutritional management— No significant change in either group at 3 mo.
Webb ^80^ 1999 | Cognitive behavioral therapy | RCT 66 | Low | Self-Management—No significant differences between groups at 3 mo.
Wysocki ^82^ 2007 | Family therapy | RCT (3 arms) 104 | Low | Adherence—Significantly higher scores for BFST-D compared to SC at each followup (up to 18 mo.); All other group differences NS; Significant main effects for groups
Zorumski ^84^ 1997 | Diabetes camp | CCT 56 | Low | Self-Management—No significant difference between groups at 4 mo.
Children with newly diagnosed diabetes
Dougherty ^18^ 1999 | General diabetes education | RCT 63 | Moderate | Adherence—No significant change for either group at 36 mo.
Siminerio ^66^ 1999 | General diabetes education | Cohort 32 | Moderate | Self-Management—Inpatient group significantly higher than outpatient group at 1 mo. For BG regulation; Outpatient group significantly higher than inpatient group at 1 mo. For emergency precautions
Children with poorly controlled diabetes
Boardway ^8^ 1993 | Cognitive behavioral therapy | RCT 31 | Low | Adherence—No significant change for either group at 6 mo.
Coupland ^15^ 1992 | General diabetes education | RCT 32 | Low | Self-management—IG significantly higher compared to CG at 6 mo. (also at 3 mo. For mean % BG testing); Adherence—IG significantly different than CG at 6 mo.
Delamater ^16^ 1991 | Cognitive behavioral therapy | RCT (3 arms) 13 | Low | Adherence—IG higher when compared to CG at 4 mo.; difference between groups was NS
Harris ^28^ 2005 | Family therapy | Before-after 18 | Low | Self-Management—No significant change at 6 mo.; Adherence—No significant change at 6 mo.
Wysocki ^83^ 2000 | Family therapy | RCT (3 arms) 119 | High | Adherence—Improvement in younger children at 3 mo. NS, effect dissipated by 6 mo.

BG = blood gas; CG = control group; IG = intervention group; NS = not significant

General population of children with diabetes—self-management and regimen adherence. Fourteen studies (10 RCTs, ^9,^ ^22,^ ^24,^ ^31,^ ^32,^ ^38,^ ^47,^ ^72,^ ^80,^ ^82^ 3 CCTs, ^48,^ ^62,^ ^84^ 1 uncontrolled before-and-after ^20^ ) assessed self-management or regimen adherence in the general population of children with type 1 diabetes. The education interventions that were assessed included general diabetes education, ^9,^ ^20,^ ^24,^ ^32,^ ^48^ cognitive behavioral therapy, ^22,^ ^31,^ ^47,^ ^72,^ ^80^ family therapy, ^38,^ ^82^ and diabetes camp. ^62,^ ^84^ In general, the methodological quality of the studies was low, with only one RCT (Szumowski ^72^ ) and one uncontrolled before-after (Greco et al. ^20^ ) rated as being of moderate quality.

Results. The RCT by Szumowski ^72^ found that children in the group that received a behavioral intervention were more compliant in performing diabetes tasks and decreased their intake of sweets compared to the control group. Other measures of self-management were unchanged in either group following the intervention. The uncontrolled before-and-after study by Greco et al. ^20^ assessed an intervention aimed at integrating teenage peers into the diabetes care of a friend with diabetes. There was not significant change in adherence scores following the intervention.

The results of the remaining studies were mixed. Two RCTs reported that groups receiving family therapy interventions ^38,^ ^82^ demonstrated increased levels of self-management or regimen adherence compared to the control group. Studies assessing interventions based cognitive behavioral therapy were inconsistent with two studies ^22,^ ^31^ reporting gains in self-management for the intervention group compared to control group and two studies ^47,^ ^80^ reporting no change following the intervention. Similarly, some studies examining general diabetes education programs reported that self-management skills improved, ^9,^ ^32^ while others found no change following the intervention. ^24,^ ^48^ The two studies that took place at diabetes camps ^62,^ ^84^ found that self-management/adherence were unchanged following camp.

### Children with Newly Diagnosed Diabetes

One RCT (Dougherty et al. ^18^ ) and one cohort study (Siminerio ^66^ ) assessed self-management or regimen adherence in the children with newly diagnosed diabetes (Table 11). The methodological quality of both studies was moderate. Both compared general diabetes education programs that were delivered in inpatient vs. ambulatory settings. Dougherty et al. found that there was no significant difference in adherence between the intervention and control groups. Siminerio reported that the inpatient group scored higher on some elements of adherence (e.g., blood glucose monitoring) but lower on others (e.g., adherence to emergency precautions). For others, there were no significant differences (e.g., adherence to food regulation and exercise).

### Children with Poorly Controlled Diabetes

The large high-quality RCT by Wysocki et al. ^83^ that assessed family therapy reported improved levels of adherence at 3 months post-intervention; the improvements disappeared by 6 months (Table 11). The results of the remaining studies were mixed. One RCT reported improved self-management/adherence compared to the control group; ^15^ one RCT found improved levels of adherence, but the difference between groups was not significant. ^16^ Two studies found that adherence was unchanged following the intervention. ^9,^ ^28^

## Psychosocial Outcomes

We identified 40 studies that assessed the effect of education on psychosocial outcomes. Of these studies, 22 examined the general population of children with diabetes, 9 focused on children with newly diagnosed diabetes and 9 considered children with poorly controlled diabetes. The psychosocial outcomes reported on were grouped into the following categories: family or social relationships (16 studies), family or social support (9 studies), social skills (3 studies), coping (14 studies), self-perception (8 studies), self-efficacy (9 studies), stress (2 studies), and anxiety and depression (6 studies).

### Family or Social Relationships

#### General Diabetes Education—Family or Social Relationships

Children with newly diagnosed diabetes. In the prospective cohort study by Srinivasan et al, ^69^ a 4- to 16-week outpatient day care program was compared with a 4- to 7-day inpatient program for delivering general diabetes education to 110 newly diagnosed patients and their families. Using the Diabetes Responsibility and Conflict Scale, there were no significant differences between the cohorts in the area of diabetes responsibility and conflict or parent-child conflict at the 12-month followup. The methodological quality of the study was moderate based on the Thomas instrument.

#### Cognitive Behavioral Therapy—Family or Social Relationships

General population of children with diabetes. Anderson et al. ^5^ assessed the effectiveness of an intervention for families that focused on teamwork and shared parent-teen responsibility for diabetes tasks. It was delivered in the form of 20- to 30-minute sessions every 3 to 4 months for 12 months. Eighty-nine families were randomly assigned to the intervention group or to one of two comparison groups: standard care (routine clinical care from the diabetes team) or standard care plus didactic diabetes education. The two comparison groups were combined to increase the power of the study. Using the Diabetes Family Conflict Scale, at the 12-month followup, the mean level of diabetes-related family conflict in the intervention group decreased significantly compared to the control group (4.8±3.09 vs. 3.8± 2.75 and 3.6± 2.6 to 3.9±2.6, respectively [p<0.02]). The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Gross et al. ^22^ randomly assigned 14 children and parents to either an intervention or control group. The intervention comprised eight weekly 90-minute sessions on self-management training for both parents and children. The control group attended eight weekly 90-minute sessions of open ended discussion for both parents and children. In both groups there were separate sessions for parents and children. The number of family-child conflicts was recorded on worksheets by parents. At 6 months post-intervention, the intervention group reported fewer conflicts than control group (1.6 conflicts vs. 0.1 conflicts per week; the control group remained at 1.1 conflicts per week). The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Szumowski ^72^ randomized 27 children and parents to either an intervention or control group. Parents and children in the control group met for six group sessions over 2 months and were given information on glucose testing, insulin injection and adjustment, diet and exercise. The intervention group received the same intervention as the control group plus they received additional instruction and practice in diabetes behavioral education and goal setting. At each assessment point, parents monitored the occurrence of diabetes-related family conflict. At the 3-month followup there was no significant change in conflict scores for either group. The methodological quality of this study was rated as moderate (2/5 on the Jadad score; unclear allocation concealment; blinding of outcome assessors).

The uncontrolled before-and-after study by Greco et al. ^20^ examined an intervention targeted at integrating peers into diabetes care. It comprised four 2-hour sessions delivered to three to six diabetes adolescent and peer pairs. Sessions included lectures and games or exercises on diabetes, problem solving, and stress management. Family conflict was assessed using the Diabetes Responsibility and Conflict Scale; information was obtained separately from parents and adolescents. The Peer Interaction Record was used to measure the adolescents' social interactions. Following the intervention, parents reported significantly less diabetes-related conflict (26.5± 8.5 vs. 23.7±6.4, p<0.05); however, the adolescents did not report a significant change. On the Peer Interaction Record, peers reported significant improvement following the intervention; however, the adolescents with diabetes did not report a significant change. The methodological quality of the study was rated as moderate based on the Thomas instrument.

Children with poorly controlled diabetes. Delamater et al. ^16^ randomized 13 patients with poor metabolic control to receive a 2-month family-based behavior therapy program or to standard outpatient care. The intervention comprised six 90-minute group sessions that focused on self-management and psychosocial skills. There were separate parent and teen sessions. Global ratings of parent-teen relationships were made using a 7-point Likert scale. At the end of the intervention, the adolescents from the intervention group showed improvement in the ratings of parent-teen relationships compared to the control group. At the 4-month followup, there was no difference between the groups. Ratings by parents in either group were unchanged over time. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

#### Family Therapy—Family or Social Relationships

General population of children with diabetes. Laffel et al. ^38^ randomly assigned 105 families to a family-focused teamwork intervention (TW) or to standard care (routine multidisciplinary clinical care). Diabetes-related conflict was measured with the Diabetes Family Conflict Scale. At the end of the 12-month program, there were no significant differences between groups on this measure. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Satin et al. ^63^ randomized 32 adolescents to one of three groups. The first group participated in a multifamily support group where families met for six weekly sessions of 90-minutes each to discuss diabetes management and feelings about diabetes and to receive group support. The second group received the same intervention plus parents participated in simulated diabetes management for one week. The third group received no intervention. Family relationships were assessed using the Family Environment Scale (FES). At the 6-month followup, there were no significant changes for any of the groups on the subscales of the FES. The methodological quality of this study was rated as low (1/5 on the Jadad score; unclear allocation concealment).

Wysocki et al. ^82^ randomized 104 families to one of three groups: standard care plus behavioral family systems therapy (BFST), standard care plus family education and support, and standard care (physician directed clinical care). Family conflict about diabetes was measured using the Diabetes Responsibility and Conflict scale. At the 12-month followup, the BFST group demonstrated a greater reduction in family conflict scores; however, the difference was not statistically significant. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Children with newly diagnosed diabetes. The RCT by Sundelin et al. ^70^ compared conventional inpatient education (n = 19 families) to a multidisciplinary program delivered in an outpatient setting (n = 19). Families in the intervention group were encouraged to move in to a training apartment for 2 weeks to receive a family-oriented crisis therapy program that developed customized management strategies based on problems and questions formulated by the family. The control group received the established clinic protocol, in which the child was hospitalized with one parent, and families were encouraged to attend information sessions with medical staff. Family and social relationships were evaluated using the Family Relations Scale and the Family Climate test. There were no statistically significant differences between groups over the 24-month followup period. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Kennedy-Iwai ^36^ randomly assigned 19 families to receive standard care (standard clinical treatment and diabetes education) or standard care plus a couple communication program delivered to parents. The effects of communication training with parents of newly diagnosed diabetic children was examined. Family relationships were measured by two subscales in the Family Environment Scale: cohesion and conflict. In the conflict subscale, mothers from the intervention group had less family conflict than mothers from the control group immediately following the intervention; however, at 3 months post-intervention this difference had disappeared. There were no differences for fathers at either time point. The methodological quality of this study was rated as low (2/5 on the Jadad score; unclear allocation concealment).

Children with poorly controlled diabetes. Wysocki et al. ^83^ randomly assigned 119 families of adolescents to three groups: standard care (physician directed clinical therapy), education and support (ES) (standard care plus 10 sessions of a diabetes support group), behavioral family systems therapy (BFST) (standard care plus family problem solving and communication training and individualized treatment plans). Family relationships were assessed with the Parent-Adolescent Relationship Questionnaire (PARQ), the Diabetes Responsibility and Conflict Scale (DRC), the Issues Checklist, and a telephone recall interview to collect descriptions of conflict situations from participants. On the PARQ, there were no significant differences between groups on the family structure subscale. On the overt conflict/skill deficits subscale and the extreme beliefs subscale, at 3-months post-intervention, the BFST group had significantly lower scores (indicating less conflict) than the standard care group, but not the ES group. On the Issues Checklist, at 6- and 12-month followups, negative communication for both adolescents and mothers significantly decreased in the BFST group compared to the other groups. As well, BFST families significantly improved on measures of negative reciprocity and problem resolution. On the DRC, the BFST group showed significantly greater improvement than the comparison groups at 6-month followup; however, this difference was not sustained at the 12-month followup. Finally, there were no significant differences for family conflict reported during recall interviews. The methodological quality of this study was rated as high (3/5 on the Jadad score; adequate allocation concealment).

In an uncontrolled before-and-after study, Harris et al. ^28^ evaluated 18 adolescents and their families who enrolled in a BFST program. Family relationships were assessed using the Diabetes Family Behavior Checklist. There were no statistically significant differences between baseline and 6-month followup measures. The methodological quality of this study was weak based on the Thomas instrument.

#### Skills Training—Family or Social Relationships

Children with newly diagnosed diabetes. One RCT by Mitchell ^49^ assessed the effect of a skill training intervention on family relationships among 32 newly diagnosed patients. The intervention group received standard multidisciplinary education and support plus a booklet targeted at improving compliance with treatment. The booklet identified problems with adherence and offered basic self-management skills. The standard care group received standard education and support. Social relationships were assessed by the externalizing behavior subscale of the Childhood Behaviour Checklist. At the 12-month followup, there were no significant differences between groups. The intervention group showed a decrease in externalizing behaviors; however, the change was not statistically significant. No change was observed for the control group. The methodological quality of the study was low (1/5 on the Jadad score; unclear concealment of allocation).

#### Diabetes Camp—Family or Social Relationships

General population of children with diabetes. The uncontrolled before-and-after study by Smith et al. ^67^ examined the effect of an intervention delivered to 120 adolescents during a 5-day diabetes camp. The objective of the intervention was to develop assertive communication and included daily 1-hour sessions that provided information, facilitated sharing, and provided opportunities to practice assertive communication, problem solving and negotiation skills. Family relationships were assessed using the Parent-Adolescent Communication Scale (P-ACS), which yields a total score and two subscale scores that measure open communication and problems in communication. Overall, at the 3-month followup, there were no significant changes in the degree of problems in communicating. However, adolescents reported a significant decrease in open communication with fathers (p<0.05). The methodological quality of the study was weak based on the Thomas instrument.

The prospective cohort study by Hill et al. ^29^ compared two different diabetes camps: one camp (n = 60) offered a program based on self-determination theory and one camp (n = 74) offered a program that had similar types of activities but was not theory-based. Social relationships were assessed using the Basic Psychological Needs Scale. At the 3-month followup, the children who attended the intervention camp reported a stronger sense of relatedness compared with the comparison camp (p = 0.03). The methodological quality of the study was weak based on the Thomas instrument.

### Summary of Results—Family or Social Relationships

Overall, we identified 16 studies that assessed the effect of diabetes education on the psychosocial outcome of family and social relationships (Table 12). Of these, nine studies (6 RCTs, 1 cohort, 2 uncontrolled before-and-after) examined the general population of children with type 1 diabetes, four studies (3 RCTs, 1 cohort) focused on children with newly diagnosed diabetes, and three (2 RCTs, 1 uncontrolled before-and-after) examined children with poorly controlled diabetes. Due to substantial differences across studies in terms of population, intervention, comparison groups, duration of intervention and followup timepoints, we were unable to pool the results of any of the studies.

Table 12 Summary of results of studies assessing the effect of diabetes education on family/social relationships

Author Year | Intervention | Study design Sample size | Quality | Results
General population of children with diabetes
Anderson ^5^ 1999 | Cognitive behavioral therapy | RCT 89 | Low | IG reported significantly less conflict than CG at 12 mo.
Greco ^20^ 2001 | Cognitive behavioral therapy | Before-after 23 | Moderate | Parents reported significantly less diabetes-related conflict following intervention; Adolescents reported no significant change in peer-interaction following intervention; Peers reported significant improvement in peer-interaction following intervention
Gross ^22^ 1985 | Cognitive behavioral therapy | RCT 14 | Low | IG reported significantly less conflict; CG remained unchanged at 6 mo.
Hill ^29^ 2006 | Diabetes camp | Cohort 134 | Low | IG reported significantly higher sense of relatedness than CG at 3 mo.
Laffel ^38^ 2003 | Family therapy | RCT 105 | Low | No significant difference in diabetes-related conflict between IG and CG (children or parents) at 12 mo.
Satin ^63^ 1989 | Family therapy | RCT 32 | Low | No significant change in family environment at 6 mo.
Smith ^67^ 1993 | Diabetes camp | Before-after 120 | Low | No significant change in degree of problems in communicating following camp; adolescents reported significant decrease in open communication with fathers following camp
Szumowski ^72^ 1990 | Cognitive behavioral therapy | RCT 27 | Moderate | No significant difference between groups in diabetes-related conflict at 3 mo.
Wysocki ^82^ 2007 | Family therapy | RCT (3 arms) 104 | Low | IG had lower family conflict scores than either CG; difference NS at 12 mo.
Children with newly diagnosed diabetes
Kennedy-Iwai ^36^ 1991 | Family therapy | RCT 19 | Low | No difference between groups for family environment or conflict at 3 mo.
Mitchell ^49^ 1996 | Skills training | RCT 32 | Low | No significant difference between groups at 12 mo.
Srinivasan ^69^ 2004 | General diabetes education | Cohort 110 | Moderate | No significant difference between groups for diabetes responsibility and conflict and parent-child conflict at 12 mo.
Sundelin ^70^ 1996 | Family therapy | RCT 38 | Low | No significant difference between groups for parent perception of child behavioral disturbances at 24 mo.; No significant difference between groups for family emotional climate at 24 mo.
Children with poorly controlled diabetes
Delamater ^16^ 1991 | Cognitive behavioral therapy | RCT 13 | Low | No significant difference between groups for parent-teen relationship at 4 mo.
Harris ^28^ 2005 | Family therapy | Before-after 18 | Moderate | No significant change from baseline to 6 mo.
Wysocki ^83^ 2000 | Family therapy | RCT (3 arms) 119 | High | PARQ overt conflict/skill deficits—IG had significantly lower scores compared to CG1 but not CG2 at 3 mo.; PARQ family structure—No significant difference between groups at 12 mo.; Parent-child division of diabetes responsibilities and family conflict—IG had significantly greater improvement than either CG at 6 mo.; difference was NS at 12 mo.; Adolescent negative communication—IG significantly improved compared to either CG at 12 mo.; Mother negative communication—IG significantly improved compared to either CG at 12 mo.; Negative reciprocity—IG showed significant improvement compared to either CG at 12 mo.; Problem resolution—IG showed significant improvement compared to either CG at 12 mo.; PARQ extreme beliefs—IG had significantly lower scores compared to either CG at 3 mo.

CG = control group; IG = intervention group; NS = not significant; PARQ = Parent-Adolescent Relationship Questionnaire

General population of children with diabetes. Nine studies (6 RCTs, ^5,^ ^38,^ ^63,^ ^72^ 1 cohort, ^29^ 2 uncontrolled before-and-after ^20,^ ^67^ ) assessed the effectiveness of diabetes education on family and social relationships in the general population of children with type 1 diabetes (Table 12). Four studies assessed the effectiveness of cognitive behavioral therapy, ^5,^ ^20,^ ^22,^ ^72^ three examined family system therapy interventions, ^38,^ ^63,^ ^82^ and two assessed the effect of diabetes camps. ^29,^ ^67^ In general, the methodological quality of the studies was low, with only one RCT ^72^ and one before-and-after study ^20^ rated as being of moderate quality.

The results of the two moderate quality studies do not suggest that diabetes education has an effect on family or social relationships. The RCT by Szumowski ^72^ compared a group that received a combination of cognitive behavior therapy and standard diabetes management training with a group that received standard diabetes management training only. There was no significant difference between the groups in diabetes-related conflict. The before-and-after study by Greco et al. ^20^ assessed an intervention aimed at integrating teenage peers into the diabetes care of a friend with diabetes. Following the intervention, peers reported improved interaction with their friend; however, no change in peer interaction was reported by the adolescents with diabetes. Parents of the adolescent with diabetes reported less diabetes-related conflict.

The results of the remaining studies were inconsistent. Three studies (2 RCTs, ^5,^ ^22^ 1 cohort ^29^ ) found that family or social relationships improved following diabetes education. In contrast, four studies (3 RCTs, ^38,^ ^63,^ ^82^ 1 uncontrolled before-and-after ^67^ ) found that the intervention had no effect on the outcome.

Children with newly diagnosed diabetes. Four studies (3 RCTs, ^36,^ ^49,^ ^70^ 1 cohort ^69^ ) assessed the effectiveness of diabetes education on family or social relationships among children with newly diagnosed diabetes (Table 12). In general, the methodological quality of the studies was low, with only the cohort study by Srinivasan ^69^ assessed as being of moderate quality. Three studies found that diabetes education was not effective in improving family or social relationships. ^36,^ ^49,^ ^69^ One study ^70^ compared the setting for delivery of a family-based education program (ambulatory vs. inpatient) and found no difference between groups on measures of family or social relationships. This was a small study and there may not have been sufficient statistical power to detect a difference between groups.

Children with poorly controlled diabetes. Three studies (2 RCTs, ^16,^ ^83^ 1 uncontrolled before-and-after ^28^ ) assessed the effectiveness of diabetes education on family or social relationships among children with poorly controlled diabetes (Table 12). The large, high-quality RCT by Wysocki et al. ^83^ assessed a family systems therapy intervention and found that the intervention group demonstrated improved levels of family conflict and communication on several of the measures used by the researchers. The remaining two studies found that the intervention had no effect on the outcome. ^16,^ ^28^

### Family or Social Support

#### General Diabetes Education—Family or Social Support

General population of children with diabetes. Brown et al. ^9^ randomized 59 children to an intervention group that viewed a diabetes-related interactive video game, or to a comparison group that received an entertainment video game with no diabetes-related content. Social support was measured by parent report of how many times in the previous month the child initiated discussions about diabetes care and about their feelings related to having diabetes. At 6-month followup, the intervention group had increased communication significantly compared to the control group (9.8±9.5 vs. 19.3±25.1 instances and 18.9±25.1 vs. 15.0±20.6 instances, respectively [p = 0.025]). The methodological quality of this study was low (1/5 on the modified Jadad scale; unclear concealment of allocation).

Children with newly diagnosed diabetes. Siminerio et al. ^66^ compared a 3- to 5-day education program delivered on an inpatient vs. outpatient basis. Patients were divided into two cohorts of 16 patients each. The education program included basic education on diabetes, complications, self-management skills, and nutrition and exercise. Family support was measured by the Coping Health Inventory for Parents, which has three subscales measuring maintenance of family integration, maintaining social support, and understanding the medical situation through consultation with medical support personnel. There were no significant differences between the groups at the 1-month followup. The methodological quality of this study was moderate using the Thomas instrument.

Children with poorly controlled diabetes. In the RCT by Coupland, ^15^ adolescents and their families participated in a family-based intervention to improve adherence (n = 15); the comparison group (n = 14) consisted of adolescents who were taught stress management techniques. Perceived diabetes-specific family support was assessed with the supportive items of the Diabetes Family Behaviour (DFB) checklist and general family support was assessed with the Family APGAR. At the 6-month followup, the intervention group reported improved general family support (p < 0.001). There was no significant difference between the two groups on the DFB checklist. The methodological quality of this study was low (2/5 on the modified Jadad scale; unclear concealment of allocation).

### Cognitive Behavioral Therapy—Family or Social Support

General population of children with diabetes. Anderson et al. ^5^ assessed the effectiveness of an intervention for families that focused on teamwork and shared parent-teen responsibility for diabetes tasks. Eighty-nine families were randomly assigned to the intervention group or to one of two comparison groups—standard care (routine clinical care from the diabetes team) or standard care plus didactic diabetes education. Family support was measured with the Diabetes Family Behavior Checklist (Unsupportive behavior subscale). At 12-month followup, the intervention group showed a significantly greater decrease in unsupportive behavior compared with the comparison groups (p<0.02). The methodological quality of this study was low (2/5 on the Jadad score; unclear concealment of allocation).

The CCT by Mendez and Belendez ^48^ used an intervention comprising 12 sessions of content delivery, skill practice and homework; parents were involved for two of the sessions. The emphasis was on reinforcement of adherence behaviors rather than punishing noncompliance. The intervention delivered to the control group care was not described. Family support was measured using the Diabetes Family Behavior Checklist. There were no significant differences between intervention and control groups for positive or negative family support at 13-month followup. The methodological quality of this study was low (1/3 on the modified Jadad score).

The uncontrolled before-and-after study by Greco et al. ^20^ delivered the intervention in 2-hour sessions over 4 weeks to groups of three to six diabetes patient-peer pairs. The intervention consisted of a review of the etiology, physiology and treatment of diabetes, reflective listening skills, problem solving related to diabetes, stress management, games or exercises to practice concepts and homework assignments. Family and peer support were measured using the Diabetes Social Support Inventory. Perceived levels of support did not improve significantly following the intervention. The methodological quality of this study was moderate based on the Thomas instrument.

Children with poorly controlled diabetes. Delamater et al. ^16^ randomized 13 adolescents to receive a 2-month behavior therapy program or to standard outpatient care. Patient and parent ratings of parental supportiveness and non-supportiveness were compared between the two groups. There were no significant differences between groups at 4-month followup. The methodological quality of this study was low (2/5 on the modified Jadad score; unclear concealment of allocation).

### Family Therapy Family or Social Support

Children with poorly controlled diabetes. In an uncontrolled before-and-after study, Harris et al. ^28^ evaluated 18 adolescents and their families who enrolled in a behavioral family systems therapy (BFST) program. Family supportive and non-supportive behaviors were assessed using the Diabetes Family Behavior Checklist. There were no statistically significant differences between baseline and 6-month followup measures. The methodological quality of this study was weak based on the Thomas instrument.

### Diabetes Camp—Family or Social Support

General population of children with diabetes. Remley ^62^ conducted a CCT (n = 237) to compare a social cognitive theory-based camp program with a standard non-theory based camp education program. Eight 1-week camps across the United States were designated to deliver either the theory-based intervention or the standard program. Social support was measured using the Diabetes Social Support index. At the 3-month followup, there were no significant changes in outcomes for either group. The methodological quality of this study was low (1/3 on the modified Jadad scale).

### Summary of Results—Family or Social Support

Overall, we identified nine studies that assessed the effect of diabetes education on the psychosocial outcome of family and social support (Table 13). Of these, five studies (2 RCTs, 2 CCTs, 1 uncontrolled before-and-after) examined the general population of children with type 1 diabetes, one cohort study focused on children with newly diagnosed diabetes, and three (2 RCTs, 1 uncontrolled before-and-after) examined children with poorly controlled diabetes.

Table 13 Summary of results of studies assessing the effect of diabetes education on family and social support

Author Year | Intervention | Study design Sample size | Quality | Results
General population of children with diabetes
Anderson ^5^ 1999 | Cognitive behavioral therapy | RCT 89 | Low | IG reported significant decreases in unsupportive behavior compared with CG at 12 mo.
Brown ^9^ 1997 | General diabetes education | RCT 59 | Low | IG significantly increased communication skills compared to CG at 6 mo.
Greco ^20^ 2001 | Cognitive behavioral therapy | Before-after 23 | Moderate | No significant change following the intervention
Mendez ^48^ 1997 | Cognitive behavioral therapy | CCT 37 | Low | No significant difference between groups on any of the social support measures at 13 mo.
Remley ^62^ 1999 | Diabetes camp | CCT 237 | Low | No significant difference between groups on any of the social support measures at 3 mo.
Children with newly diagnosed diabetes
Siminerio ^66^ 1999 | General diabetes education | Cohort 32 | Moderate | No significant difference between groups at 1 mo.
Children with poorly controlled diabetes
Coupland ^15^ 1992 | General diabetes education | RCT 32 | Low | No significant difference between groups at 6 mo.
Delamater ^16^ 1991 | Cognitive behavioral therapy | RCT 13 | Low | No significant difference between groups on any of the social support measures at 4 mo.
Harris ^28^ 2005 | Family therapy | Before-after 18 | Low | No significant change at 6 mo. for diabetes support; No significant change at 6 mo. for diabetes non-support

CG = control group; IG = intervention group

General population of children with diabetes. Five studies (2 RCTs, ^5,^ ^9^ 2 CCTs, ^48,^ ^62^ 1 uncontrolled before-and-after ^20^ ) assessed the effectiveness of diabetes education on family and social support in the general population of children with type 1 diabetes (Table 13). Three studies assessed the effectiveness of cognitive behavioral therapy, ^5,^ ^20,^ ^48^ one examined general diabetes education, ^9^ and one assessed the effect of diabetes camps. ^120^ In general, the methodological quality of the studies was low, with only the before-and-after study by Greco et al. ^20^ rated as being of moderate quality.

The uncontrolled before-and-after study by Greco et al. ^20^ assessed an intervention aimed at integrating teenage peers into the diabetes care of a friend with diabetes. There was no change in perceived levels of family support following the intervention. The results of the remaining studies were inconsistent. Two RCTs, ^5,^ ^9^ found that family/social support improved following diabetes education. In contrast, two CCTs ^48,^ ^62^ found that the intervention had no effect on the outcome.

Children with newly diagnosed diabetes. The moderate quality cohort study by Siminerio et al. ^66^ compared inpatient vs. ambulatory delivery of general diabetes education among children with newly diagnosed diabetes (Table 13). There were no significant differences between groups for the family/social support outcome.

Children with poorly controlled diabetes. Three studies (2 RCTs, ^15,^ ^16^ 1 uncontrolled before-and-after ^28^ ) assessed the effectiveness of diabetes education on family/social support among children with poorly controlled diabetes (Table 13). The methodological quality of the studies was low. None of the studies found that the intervention had an effect on the outcome.

### Social Skills

#### General Diabetes Education—Social Skills

Children with poorly controlled diabetes. Nunn et al. ^55^ conducted a RCT to assess the effect of a general diabetes education intervention on social skills. One hundred and twenty-three patients were randomized to either the intervention group, comprising 15- to 30-minute telephone calls on three main topics: current insulin, carbohydrate intake and blood glucose values; events which may impact diabetes management; and delivery of an educational program, or to the standard care group (routine clinical care). Social skills were measured using the Strengths and Difficulties Questionnaire. At the end of the 5- to 8-month program, there were no significant differences between groups for various social skills (emotional, conduct, hyperactive, peer problem, and pro-social scores). The methodological quality of the study was high (3/5 on the Jadad score; unclear concealment of allocation)

In the CCT by Viner et al. ^76^ a 6-week motivational and solution-focused therapy group program that used systematic questions, a narrative approach and cognitive behavioral therapy was delivered to 21 adolescents and their parents. The control group comprised 20 adolescents who did not receive any intervention. Social skills were assessed using the Strengths and Difficulties Questionnaire (SDQ). There were no significant changes in mean SDQ scores for either group. The methodological quality of the study was low (2/5 on the Jadad score; unclear concealment of allocation).

#### Cognitive Behavioral Therapy—Social Skills

General population of children with diabetes. Gross et al. ^23^ randomized six children to a social skills training intervention and five to a control group. The social skills training consisted of modeling and role-playing exercises and took place in two 45-minute per week sessions for 5 weeks. The control group subjects did not interact with the experimenters except at assessment times (baseline, post training, one and six-week followups). At the 6-week followup, the intervention group demonstrated increased incidence of certain social skills, including percentage eye contact time (from 53 to 95 percent), percentage verbalizations (from 24 to 79 percent), and speech duration (from 1.7 to 6 seconds). There were no changes observed in these behaviors for the control group. The methodological quality of the study was moderate (2/5 on the Jadad score; unclear concealment of allocation; blinding of outcome assessors).

### Summary of Results—Social Skills

General population of children with diabetes. One moderate quality RCT (Gross et al. ^23^ ) assessed the effect of cognitive behavioral therapy on social skills in the general population of children with type 1 diabetes (Table 14). They found that the intervention group significantly improved their social skills compared to the control group.

Table 14 Summary of results of studies assessing the effect of diabetes education on social skills

Author Year | Intervention | Study design Sample size | Quality | Results
General population of children with diabetes
Gross ^23^ 1983 | Cognitive behavioral therapy | RCT 11 | Moderate | IG improved significantly for increased eye contact, appropriate verbalization, speech duration, affect ratings at 6 wk.; no change for CG
Children with poorly controlled diabetes
Nunn ^55^ 2006 | General diabetes education | RCT 123 | High | No significant change for either group at 5–8 mo. in emotional, conduct, hyperactive, peer problem, and pro-social scores
Viner ^76^ 2003 | Cognitive behavioral therapy | CCT 21 | Low | No significant change for either group at 12 mo.

CG = control group; IG = intervention group

Children with poorly controlled diabetes. The large high quality RCT by Nunn et al, ^55^ reported no significant differences in social skills between the intervention group that received general diabetes education plus telephone followup and the control group that received diabetes education with no telephone followup (Table 14). Similarly, the CCT that assessed this population did not find any change in social skills. ^76^

### Coping

#### General Diabetes Education—Coping

General population of children with diabetes. In the uncontrolled before-and-after study by Marteau et al., ^44^ a multidisciplinary team delivered a weekend program to 97 parents. There were sessions on problem solving, forming self-help groups, and ways to achieve best care. Parents rated themselves as significantly more confident in looking after their child both immediately following the intervention and at the 3-month followup. However, their perception of the difficulty of looking after their child remained unchanged at 3-months post-intervention. The methodological quality of this study was rated as weak based on the Thomas instrument.

Children with newly diagnosed diabetes. Dougherty et al. ^18^ delivered a general diabetes education intervention to 63 newly diagnosed patients. Thirty-one patients were randomized to receive the education as inpatients; the other 32 received their education at home in the form of home visits. At 24 months following diagnosis, there was no significant difference between groups on the Impact on Family Scale. The methodological quality of the study was moderate (2/5 on the Jadad score; unclear concealment of allocation; blinding of outcome assessors).

Siminerio et al. ^66^ compared a 3- to 5-day education program delivered on an inpatient vs. outpatient basis. Patients were divided into two cohorts of 16 patients each. The education program included basic education on diabetes, complications, self management skills, and nutrition and exercise. At 1-month post-intervention, there were no significant differences between the groups in coping as measured by the Coping Health Inventory for Parents and the Coping Health Inventory for Children questionnaires. The methodological quality of this study was rated as moderate based on the Thomas instrument.

In a prospective cohort study by Srinivasan et al., ^69^ a 4- to 16-week outpatient day care program was compared with a 4- to 7-day inpatient program for delivering general diabetes education to 110 newly diagnosed patients and their families. There was no difference between groups for the outcome of coping. The methodological quality of this study was rated as moderate based on the Thomas instrument.

#### Cognitive Behavioral Therapy—Coping

General population of children with diabetes. The RCT by Grey et al. ^21^ examined a coping skills training intervention in a group of 77 adolescents that received intensive diabetes management as their standard care. Forty-one children were randomized to the coping skills training group and the training was delivered at 6 weekly sessions. Based on the Issues in Coping with IDDM scale, at 12-month followup, both groups reported significantly less upset about coping with diabetes and found it significantly less difficult to cope with their diabetes. The difference between the groups was not statistically significant. The methodological quality of the study was moderate (2/5 on the Jadad score; unclear concealment of allocation; blinding of outcome assessors).

The CCT by Mendez and Belendez ^48^ used an intervention comprising 12 sessions of content delivery, skill practice and homework assignment; parents were involved for two of the sessions. The emphasis was on reinforcement of adherence behaviors rather than punishing noncompliance. The intervention delivered to the control group care was not described. The questionnaires used were the Diabetic Daily Hassles Scale and the Diabetic Adolescents Social Skills Inventory. The authors reported that the intervention group had a significantly lower incidence of daily diabetes-related hassles and a lower degree of unease and likelihood of response in a social interaction relating to diabetes at post-intervention and 13-month followup. The methodological quality of the study was low (1/3 on the modified Jadad score).

The uncontrolled before-and-after study by Greco et al. ^20^ delivered the intervention in 2-hour sessions over 4 weeks to groups of three to six diabetes patient-peer pairs. The intervention consisted of homework review on etiology, physiology and treatment of diabetes, reflective listening skills, problem solving related to diabetes, stress management, games or exercises to practice concepts and homework assignments. Using the Teen Adjustment to Diabetes Scale, the authors reported a trend toward improved behavioral, affective, and attitudinal adjustment to diabetes post-intervention; however, the change was not statistically significant. The methodological quality of this study was rated as moderate based on the Thomas instrument.

Children with poorly controlled diabetes. In a three-arm RCT (n = 37) Cigrang ^13^ investigated the effects of a coping skills program delivered to adolescents with a history of poor metabolic control. There were two comparison groups: conventional diabetes education (8 lectures on diabetes topics including a question and answer session and time for skills practice) and standard care (routine clinical visits). The intervention group received eight sessions that focused on identifying issues that were perceived as difficult and stressful and developing adaptive coping strategies; the group was asked to implement new coping strategies in real life situations during the week. At 3-months followup, there were no significant differences among any of the groups for the outcome of coping using the Acceptance of Illness scale. The methodological quality of the study was low (2/5 on the Jadad score; unclear concealment of allocation).

Boardway et al. ^8^ randomized 31 children to either a 3-month stress management program or to standard outpatient care. The intervention included group sessions in three phases of self-monitoring, stress management and regimen adherence. At the 6-month followup, there were no significant differences between the groups on the Ways of Coping questionnaire. The methodological quality of the study was low (1/5 on the Jadad score; unclear concealment of allocation).

Hains et al. ^25^ randomly assigned 15 adolescents to a 3-phase stress inoculation program or to a control group that received no intervention. At the 1-month followup, there was no difference between groups on the KIDSCOPE questionnaire. The methodological quality of the study was low (2/5 on the Jadad score; unclear concealment of allocation).

#### Family Therapy—Coping

Children with poorly controlled diabetes. Wysocki et al. ^83^ randomly assigned 119 families to three groups: standard care (physician directed clinical therapy), education and support (standard care plus 10 sessions of a diabetes support group), and behavioral family systems therapy (BFST) (standard care plus family problem solving and communication training and individualized treatment plans). No significant difference was found among the groups for the outcome of coping at any time point up to 12-months post-intervention. The methodological quality of the study was rated as high (3/5 on the Jadad score; adequate allocation of concealment).

#### Skills Training

Children with newly diagnosed diabetes. One RCT by Mitchell ^49^ assessed the effect of a skills training intervention on coping abilities among 32 newly diagnosed patients (mean age 10.7 years). The intervention group received standard multidisciplinary education and support plus a booklet targeted at improving compliance with treatment. The booklet identified problems with adherence and offered basic self-management skills. The standard care group received standard education and support. Using the Problem Situations Questionnaire, at the 12-month followup there were no significant differences in coping outcomes between the groups. The methodological quality of the study was low (1/5 on the Jadad score; unclear concealment of allocation).

#### Diabetes Camp—Coping

General population of children with diabetes. The uncontrolled before-and-after study by Koontz ^37^ (n = 112) took place during a 1-week camp. Children were distributed in study groups according to age (grades 2–5, 6–8, and 9–10). The intervention included education on self-management skills, insulin administration, the relationship between diet, exercise and insulin, meal and snack planning, selecting and measuring food portions, SMBG, and identifying and treating insulin reactions, and was aimed to enhance camper's emotional adjustment and improve self-esteem. At the 3-month followup, there was no effect of the intervention on coping strategies. However, the author noted that coping strategies differed as a function of age. The methodological quality of the study was moderate based on the Thomas instrument.

The intervention in the uncontrolled before-and-after study by Smith ^68^ (n = 108) consisted of daily 1-hour sessions on stress and diabetes in which management techniques were described, modeled and practiced using a variety of techniques. There was no significant change in coping abilities from pre- to post-camp. The methodological quality of the study was weak based on the Thomas instrument.

### Summary of Results—Coping

Overall we identified 14 studies that examined the psychosocial outcome of coping (Table 15). Of these, six studies (1 RCT, 1 CCT, 4 uncontrolled before-and-after) examined the general population of children with type 1 diabetes. Four studies (2 RCTs, 2 cohorts,) focused on children with newly diagnosed diabetes. Four RCTs targeted children with poorly controlled diabetes.

Table 15 Summary of results of studies assessing the effect of diabetes education on coping

Author Year | Intervention | Study design Sample size | Quality | Results
General population of children with diabetes
Greco ^20^ 1991 | Cognitive behavioral therapy | Before-after 23 | Moderate | Trend toward improved behavioral, affective, and attitudinal adjustment; difference was NS
Grey ^21^ 2000 | Cognitive behavioral therapy | RCT 77 | Moderate | Both groups reported less upset about coping with diabetes and less difficult to cope with diabetes at 12 mo.; difference between groups was NS
Koontz ^37^ 2002 | Diabetes camp | Before-after 112 | Moderate | No significant change at 3 mo.
Marteau ^44^ 1987 | General diabetes education | Before-after 97 | Low | Parents rated themselves significantly more confident in looking after their child at 3 mo.; Parents perception of difficulty in looking after child did not change at 3 mo.
Mendez ^48^ 1997 | Cognitive behavioral therapy | CCT 37 | Low | IG reported significantly fewer daily diabetes-related hassles at 13 mo.; IG reported significantly lower degree of unease and likelihood of response in social situation relating to diabetes at 13 mo.
Smith ^68^ 1991 | Diabetes camp | Before-after 108 | Low | No significant change from pre- to post-camp
Children with newly diagnosed diabetes
Dougherty ^18^ 1999 | General diabetes education | RCT 63 | Moderate | No significant difference between groups on family impact at 24 mo.
Mitchell ^49^ 1996 | Skills | RCT 32 | Low | No significant differences between groups in perceived difficulties in diabetes management at 12 mo.; No significant differences between groups in social function and general adjustment at 12 mo.
Siminerio ^66^ 1999 | General diabetes education | Cohort 32 | Moderate | No significant difference between groups at 1 mo.
Srinivasan ^69^ 2004 | General diabetes education | Cohort 110 | Moderate | No significant difference between groups at 12 mo.
Children with poorly controlled diabetes
Boardway ^8^ 1993 | Cognitive behavioral therapy | RCT 31 | Low | No significant difference between groups at 6 mo.
Cigrang ^13^ 1992 | Cognitive behavioral therapy | RCT 37 | Low | No significant difference between groups at 3 mo.
Hains ^25^ 2000 | Cognitive behavioral therapy | RCT 15 | Low | No difference between groups at 1 mo.
Wysocki ^83^ 2000 | Family therapy | RCT 119 | High | No significant difference between groups at 12 mo.

CCT = controlled clinical trial; IG = intervention group; NS = not significant

General population of children with diabetes. Six studies (1 RCT, ^21^ 1 CCT, ^48^ 4 uncontrolled before-and-after ^20,^ ^37,^ ^44,^ ^68^ ) assessed the effect of diabetes education on coping in the general population of children with diabetes (Table 15). Three studies assessed the effectiveness of cognitive behavioral therapy, ^20,^ ^21,^ ^48^ one examined general diabetes education, ^44^ and two assessed the effect of diabetes camps. ^37,^ ^68^ In general the methodological quality of the studies was low, with only one RCT (Grey et al. ^21^ ) and two uncontrolled before-after studies (Greco et al. ^20^ and Koontz ^37^ ) rated as being of moderate quality.

The results of the three moderate quality studies do not suggest that diabetes education has an effect on coping abilities. The RCT by Grey et al. ^21^ found that both the intervention and control groups reported improved coping abilities; however, the difference between groups was not statistically significant. Similarly, the before-after studies Koontz ^37^ and Greco et al. ^20^ did not find that coping abilities were significantly improved following the education interventions.

The results of the remaining studies were mixed. One uncontrolled before-and-after study found that parents were more confident about their ability to care for their children. ^44^ One CCT that focused on improving adherence behavior and stress management had a significant impact on coping abilities. ^48^ One uncontrolled before-and-after studies that assessed the effect of an intervention delivered at diabetes camps found no change in coping behaviors. ^68^

Children with newly diagnosed diabetes. Three moderate quality studies (1 RCT ^18^ and 2 prospective cohort studies ^66,^ ^69^ ) examined whether the setting for delivery of general diabetes education (i.e., delivery of education in an inpatient setting vs. an ambulatory setting) had an impact on coping behaviors (Table 15). None of the studies reported significant group differences in coping outcomes. The remaining study assessed a skills training intervention and found no difference between study groups. ^49^

Children with poorly controlled diabetes. The large high-quality RCT by Wysocki et al, ^83^ reported no significant differences in coping behaviors between the intervention group that received behavioral family systems therapy and the control groups that received standard care and education support (Table 15). Similarly, the remaining low quality studies did not report any significant differences between intervention and control groups. ^8,^ ^13,^ ^25^

### Self-Perception

#### Cognitive Behavioral Therapy—Self-Perception

General population of children with diabetes. The uncontrolled before-and-after study by Greco et al. ^20^ delivered the intervention in 2-hour sessions over 4 weeks to group of three to six diabetes patient-peer pairs. The intervention comprised information about diabetes, reflective listening skills, problem solving, stress management, and games or exercises to practice concepts. Self-perception was assessed using the global self-worth scale of the Self Perception Profile. At the end of the intervention, there was no significant change from baseline in self-perception among adolescents with diabetes. The methodological quality of this study was moderate based on the Thomas instrument.

Thomas-Dobersen et al. ^74^ conducted a CCT in which 11 obese adolescents participated in the SHAPEDOWN program which included 14 sessions over 3 months addressing various aspects of diabetes management such as diet and knowledge of hypoglycemia. The control group (n = 9) received standard diabetes treatment. Self-esteem was measured using the global self-esteem scale of the Self Perception Profile. At 15 months, more children in the intervention group (4/11) showed clinical improvement in their self-perception compared to the control group (1/9). The methodological quality of this study was low (1/3 on the modified Jadad score).

Children with poorly controlled diabetes. In a 3-arm RCT, Cigrang ^13^ investigated the effects of a coping skills program delivered to 37 adolescents with a history of poor metabolic control. There were two comparison groups: conventional diabetes education and standard care. Self-perception was assessed using the Self Perception Profile for Children. At 3-months post-intervention there were no significant differences among the three groups. The methodological quality of this study was low (2/5 on the Jadad score; unclear allocation concealment).

#### Diabetes Camp—Self-Perception

General population of children with diabetes. In a CCT, Zorumski ^84^ assigned 56 children to attend either a 1-week camp that used active participation and educational presentations to teach all aspects of diabetic self-management, or to a control group that received standard clinical care but did not attend a camp. At the 4-month followup, the intervention group had a significantly lower score in self-perception (i.e., did not improve) compared to their baseline level (3.52±0.55 vs. 3.41±0.50), whereas the control group improved their score over the same time period (3.27±0.63 to 3.56±0.52). The methodological quality of this study was low (0/3 on the modified Jadad score).

The uncontrolled before-and-after study by Koontz ^37^ (n = 112) took place during a 1-week camp. Participants were divided into 3 age groups (grades 2–5, 6–8, and 9–10). The intervention included education on self-management skills, insulin administration the relationship between diet, exercise and insulin, meal and snack planning and food portions, SMBG, and identifying and treating insulin reactions. Several subscales of the Self Perception Profile were used: social competence, physical attractiveness, athletic ability and global self-worth. At the 3-month followup, there were no significant differences in social competence and physical attractiveness within or between groups. Campers in the two younger age groups felt more athletically competent than those in the oldest group. Among the older campers, global self-worth decreased over the 3-month followup period; for younger campers, this attribute increased. The methodological quality of this study was moderate based on the Thomas instrument.

In an uncontrolled before-and-after study, Smith et al. ^67^ used the Adolescent Self Expression scale to measure changes in assertive behavior among adolescents attending a diabetes camp. At the 3-month followup, there was a significant increase in perception of assertive behavior. The methodological quality of this study was weak based on the Thomas instrument.

#### Family Therapy—Self-Perception

Children with newly diagnosed diabetes. The RCT by Sundelin et al. ^70^ compared conventional inpatient education (n = 19 families) to a multidisciplinary program for family-oriented crisis intervention delivered in an outpatient setting (n = 19 families). Self-esteem was measured using the “I think I am” test. At 24-month followup, there was no statistically significant difference between groups on this measure. The methodological quality of this study was low (2/5 on the Jadad score; unclear allocation concealment).

Children with poorly controlled diabetes. In the uncontrolled before-and-after study by Harris et al. ^28^ reported 6-month followup data for 18 families who enrolled in a BFST program. Self-perception was measured using the Adjustment to Illness Scale which assesses feelings of self-acceptance and acceptance by others despite their illness. There were no significant differences in adjustment scores between baseline and 6-month followup for adolescents, mothers or fathers. The methodological quality of this study was weak based on the Thomas instrument.

## Summary of Results—Self-perception

### General Population of Children with Diabetes

Five studies (2 CCTs, ^74,^ ^84^ 3 uncontrolled before-and-after ^20,^ ^37,^ ^67^ ) examined the effect of diabetes education on self-perception in the general population of children with type 1 diabetes (Table 16). Three studies examined interventions based on cognitive behavioral techniques ^20,^ ^67,^ ^74^ and two assessed intervention delivered at a diabetes camp. ^37,^ ^67^ Overall the methodological quality of the studies was low, with only two uncontrolled before-and-after studies considered to be of moderate quality (Greco et al. ^20^ and Koontz ^37^ ).

Table 16 Summary of results of studies assessing the effect of diabetes education on self-perception

Author Year | Intervention | Study design Sample size | Quality | Results
General population of children with diabetes
Greco ^20^ 2001 | Cognitive behavioral therapy | Before-after 23 | Moderate | No significant change in social, academic, job, behavior, athletic competence
Koontz ^37^ 2002 | Diabetes camp | Before-after 112 | Moderate | No significant change in social competence and physical attractiveness at 3 mo.; Younger campers felt more athletically competent than older campers at 3 mo.
Smith ^67^ 1993 | Cognitive behavioral therapy | Before-after 120 | Low | Significant increase in assertive behavior at 3 mo.
Thomas-Dobersen ^74^ 1993 | Cognitive behavioral therapy | CCT 20 | Low | 4/11 IG subjects showed improvement at 15 mo. compared to 1/9 in CG; significance NR
Zorumski ^84^ 1997 | Diabetes camp | CCT 56 | Low | IG had significantly lower score than CG at 4 mo.
Children with newly diagnosed diabetes
Sundelin ^70^ 1996 | Family therapy | RCT 38 | Low | No significant difference between groups at 24 mo.
Children with poorly controlled diabetes
Cigrang ^13^ 1992 | Cognitive behavioral therapy | RCT 37 | Low | No significant difference between groups at 3 mo.
Harris ^28^ 2005 | Family therapy | Before-after 18 | Moderate | No significant change in self acceptance or acceptance by others at 6 mo.

CG = control group; IG = intervention group; NR = not reported

With the exception of one uncontrolled before-and-after study, ^67^ none of the studies found that diabetes education had an effect on self-perception.

Children with newly diagnosed diabetes. One study ^70^ compared the setting for delivery of a family-based education program (ambulatory vs. inpatient) and found no difference between groups on measures of self-perception (Table 16). This was a small study and there may not have been sufficient statistical power to detect a difference between groups.

Children with poorly controlled diabetes. Two studies ^13,^ ^28^ examined the effect of diabetes education on self-perception among children with poorly controlled diabetes. Neither study found that the education intervention had an effect on self-perception (Table 16).

### Self-Efficacy

#### General Diabetes Education—Self-Efficacy

General population of children with diabetes. Brown et al. ^9^ randomized 59 children to receive either a diabetes related interactive video game (intervention group), or an entertainment video game with no diabetes related content (control group). Perceived self-efficacy was evaluated using a validated yielding a self-efficacy score from 1 to 7. Assessments took place at baseline, 3 and 6 months. The intervention group improved relative to the control group on self-efficacy ratings (0.45±0.60 vs. 0.17±0.57, respectively), but this change was not significant (p = 0.07). The methodological quality of the study was low (1/5 on the Jadad score; unclear allocation of concealment).

Children with newly diagnosed diabetes. In the study by Hoff et al. ^30^ 46 parents of children newly diagnosed with diabetes (mean age = 9.4 years) were randomly assigned to the intervention or control group. The intervention was delivered to parents and comprised two 2.5-hour group sessions designed to teach skills to manage uncertainty and to decrease parental distress and child behavioral problems. Parents assigned to the control group did not receive an intervention. Self-efficacy regarding dealing with the child's illness was assessed using the Parent Perception of Uncertainty Scale. At the 3- and 6-month followup assessments, there were no significant changes for mothers and fathers in either group. The methodological quality of the study was high (3/5 on the Jadad score; adequate allocation of concealment).

### Cognitive Behavioral Therapy—Self-Efficacy

General population of children with diabetes. The RCT by Grey et al. ^21^ randomized 77 children to either a coping skills training combined with intensive diabetes management or to standard care (intensive management only). Self-efficacy was measured using the Self Efficacy for Diabetes Scale. At 12 months, adolescents in both groups reported significantly improved general, medical, and diabetes self-efficacy. The intervention group had significantly better diabetes and medical self-efficacy compared to the control group. The methodological quality of the study was moderate (2/5 on the Jadad score; unclear allocation of concealment; blinding of outcome assessors).

Children with newly diagnosed diabetes. Boardway et al. ^8^ randomized 31 children to either a 3-month stress management program or to standard outpatient care. The intervention included group sessions in three phases of self-monitoring, stress management and regimen adherence. Self-efficacy was measured using the Self-Efficacy for Diabetes Scale. At the 3-month followup, there were no significant changes in self-efficacy. The methodological quality of the study was low (1/5 on the Jadad score; unclear allocation of concealment).

Children with poorly controlled diabetes. In the CCT (n = 21), Viner et al. ^76^ used motivational and solution focused therapy techniques for their intervention group compared to a no treatment control group. Self-efficacy was measured using the Self-Efficacy for Diabetes (SED) Scale. Mean SED scores improved significantly from baseline to the 6-month followup for the intervention group compared to no change in the control group. The methodological quality of the study was low (1/3 on the modified Jadad score).

### Skills Training—Self-Efficacy

General population of children with diabetes. In an uncontrolled before-and-after study by Caravalho and Saylor, ^11^ 56 children and their parents were taught insulin adjustment procedures and received group support and education to improve self-management. Self-efficacy was assessed using the 13-item adapted Self-Efficacy for Diabetes Parent Questionnaire. After the 1-year intervention, self-efficacy scores had increased significantly from 56.2±7.7 to 59.3±6.9 (p = 0.01). The methodological quality of the study was weak using the Thomas instrument.

### Diabetes Camp—Self-Efficacy

General population of children with diabetes. Remley ^62^ conducted a CCT (n = 237) to compare a social cognitive theory-based program with a standard non-theory based camp education program. Eight 1-week camps across the United States were designated to deliver either the theory-based intervention or the standard program. At the end of the camp and at the 3-month followup, there was no significant difference in self-efficacy for either group. The methodological quality of the study was low (1/3 on the modified Jadad score).

In an uncontrolled before-and-after study, Schlundt et al. ^64^ delivered an intervention to 86 campers. The program consisted of two sessions and used a 17-minute video on obstacles faced by adolescents with diabetes. Campers identified, analyzed and proposed solutions and then attempted to apply them to their own lives. Self-efficacy was measured by Self Efficacy for Diabetes (SED) Scale and the Situational Obstacles to Dietary Adherence (SODA) questionnaire. No change in the SED score occurred in either group from baseline to end of the 2-week camp. However, the SODA questionnaire indicated that children had significant increases in confidence to handle dietary obstacles. The methodological quality of the study was weak using the Thomas instrument.

The prospective cohort study by Hill et al. ^29^ compared two different diabetes camps: one camp (n = 60) offered a program based on self-determination theory and one camp (n = 74) offered a program that had similar types of activities but was not theory-based. Self-efficacy was assessed with a Treatment Self Regulation Scale and a Perceived Confidence scale. At 3-month followup there were no significant differences between the intervention and comparison groups in perceived competence for diabetes management. There was a significant decrease in autonomy for diabetes management in the intervention group vs. and increase in autonomy for the comparison group the intervention group. The methodological quality of the study was weak based on the Thomas instrument.

### Summary of Results—Self-Efficacy

General population of children with diabetes. Six studies (2 RCTs, ^9,^ ^21^ 1 CCT, ^62^ 1 cohort, ^29^ 2 uncontrolled before-and-after ^11,^ ^64^ ) examined the effect of diabetes education on self-efficacy in the general population of children with type 1 diabetes (Table 17). Three studies examined interventions delivered at diabetes camp ^29,^ ^62,^ ^64^ and 1 each studied general diabetes education, ^9^ cognitive behavioral therapy, ^21^ and skills training. ^11^ Overall the methodological quality of the studies was low, with only one RCT assessed as being of moderate quality (Grey et al. ^21^ ).

Table 17 Summary of results of studies assessing the effect of diabetes education on self-efficacy

Author Year | Intervention | Study design Sample size | Quality | Results
General population of children with diabetes
Brown ^9^ 1997 | General diabetes education | RCT 59 | Low | Both groups improved; difference was NS at 6 mo.
Caravalho ^11^ 2000 | Skills training | Before-after 56 | Low | Significant improvement in scores at 12 mo.
Grey ^21^ 2000 | Cognitive behavioral therapy | RCT 77 | Moderate | Both groups showed significant improvement in general self-efficacy at 12 mo.; IG did significantly better for diabetes and medical self-efficacy than CG at 12 mo.
Hill ^29^ 2006 | Diabetes camp | Cohort 134 | Low | No significant difference between groups in competence or degree of autonomy at 3 mo.
Remley ^62^ 1999 | Diabetes camp | CCT 237 | Low | No significant difference between groups at 3 mo.
Schlundt ^64^ 1996 | Diabetes camp | Before-after 86 | Low | Statistically significant increase in confidence to overcome diabetes-related obstacles; No significant change in patient belief in self-care abilities
Children with newly diagnosed diabetes
Hoff ^30^ 2005 | General diabetes education | RCT 46 | High | No significant difference between groups at 6 mo.
Children with poorly controlled diabetes
Boardway ^8^ 1993 | Cognitive behavioral therapy | RCT 31 | Low | No significant difference between groups at 3 mo.
Viner ^76^ 2003 | Cognitive behavioral therapy | CCT 21 | Low | Significant improvement for IG at 6 mo.; no change for CG intervention

CG = control group, IG = intervention group; NS = not significant

The RCT by Grey et al. ^21^ reported that the cognitive behavioral intervention had a positive effect on self-efficacy. The results of the remaining studies were mixed. Two studies found self-efficacy improved following the intervention. ^11,^ ^64^ One found that both the intervention and control groups improved, but the difference between groups was not statistically significant. ^9^ The remaining studies reported no change in self-esteem measures following the education intervention. ^29,^ ^62^

Children with newly diagnosed diabetes. The high quality RCT by Hoff et al. ^30^ assessed an intervention delivered to parents of children with newly diagnosed diabetes to help them manage the uncertainty of how to care for their children (Table 17). There was no significant difference in parental self-efficacy between the intervention and control groups. The remaining study examined the effect of a stress management program on self-efficacy among children with newly diagnosed diabetes and found no difference between the intervention and control groups. ^8^

Children with poorly controlled diabetes. One low quality CCT ^76^ found that an intervention based on cognitive behavior therapy techniques resulted in improved levels of self-efficacy among children with poorly controlled diabetes (Table 17).

## Stress

### Cognitive Behavioral Therapy—Stress

Children with poorly controlled diabetes. Boardway et al. ^8^ randomized 31 adolescents to either a 3-month stress management program or to a control group that received standard outpatient care. Stress was measured using the Diabetes Stress Questionnaire (DSQ). At the 6-month followup, the intervention group reported significantly improved stress levels compared to the control group (93.6±39.0 vs. 56.1±43.7 and 88.4±33.5 vs. 83.4±31.3, respectively). The methodological quality of the study was low (1/5 on the Jadad score; unclear concealment of allocation).

The RCT by Hains et al. ^25^ randomized 15 middle school children to either a stress inoculation training program delivered over 6 weeks or to a waiting list control group. Stress was measured using the DSQ. At 1-month followup, the intervention group showed improvement in stress levels compared to the control group; however, the difference between the groups was not statistically significant. The methodological quality of the study was low (2/5 on the Jadad score; unclear concealment of allocation).

### Summary of Results—Stress

Two RCTs assessed the effect of cognitive behavioral therapy interventions on stress among children with poorly controlled diabetes (Table 18). ^8,^ ^25^ and found that the interventions groups had reduced stress levels compared to the control groups. However, the methodological quality for both studies was low and the results must be interpreted with caution.

Table 18 Summary of results of studies assessing the effect of diabetes education on stress

Author Year | Intervention | Study design Sample size | Quality | Results
Children with poorly controlled diabetes
Boardway ^8^ 1993 | Cognitive behavioral therapy | RCT 31 | Low | IG had significantly reduced stress levels compared to CG at 6 mo.
Hains ^25^ 2000 | Cognitive behavioral therapy | RCT 15 | Low | IG had reduced stress levels compared to CG at 1 mo; difference was NS

CG = control group, IG = intervention group; NS = not significant

### Anxiety and Depression

#### General Diabetes Education—Anxiety and Depression

Children with newly diagnosed diabetes. In the study by Hoff et al. ^30^ 46 parents of children newly diagnosed with diabetes were randomly assigned to the intervention or control group. The intervention was delivered to parents and comprised two 2.5-hour group sessions designed to teach skills to manage uncertainty and to decrease parental distress and child behavioral problems. Parents assigned to the control group did not receive an intervention. Children continued to receive routine clinical care and intensive education. Mothers in the intervention group reported decreased child internalizing problems at the 1- and 6-month followup points; mothers in control group did not report any changes. Conversely, fathers in the intervention group did report changes in child internalizing problems during followup; however, fathers in the control group reported decreased child decreased child internalizing problems at the 1-month followup. This change disappeared at the 6-month followup. The methodological quality of the study was high (3/5 on the Jadad score; adequate concealment of allocation).

#### Cognitive Behavioral Therapy—Anxiety and Depression

General population of children with diabetes. The RCT by Grey et al. ^21^ examined a coping skills training intervention in a group of 77 adolescents who received intensive diabetes management as their standard care. Forty-one children were randomized to the coping skills training group and the training was delivered at six weekly sessions. Using the Children's Depression Inventory, at the 12-month followup, both groups reported significantly less depression; however, the difference between the groups was not statistically significant. The methodological quality of the study was moderate (2/5 on the Jadad score; unclear concealment of allocation; blinding of outcome assessors).

Children with poorly controlled diabetes. In a three-arm RCT (n = 37) Cigrang ^13^ investigated the effects of a coping skills program delivered to adolescents with a history of poor metabolic control. There were two comparison groups: conventional diabetes education (eight lectures on diabetes topics including a question and answer session and time for skills practice) and standard care (routine clinical visits). The intervention group received eight sessions that focused on identifying issues that were perceived as difficult and stressful and developing adaptive coping strategies; the group was asked to implement new coping strategies in real life situations during the week. Immediately following the intervention, there were no significant differences among any of the groups on measures of depression from the Dimensions of Depression Profile. The methodological quality of the study was low (2/5 on the Jadad score; unclear concealment of allocation).

Hains et al. ^25^ randomly assigned 15 adolescents to a 3-phase stress inoculation program delivered to patients and parents or to a control group that received no intervention. Anxiety was measured using the State-Trait Anxiety Inventory. At 1-month followup, there were no significant decreases in anxiety for either group. The methodological quality of the study was low (2/5 on the Jadad score; unclear concealment of allocation).

#### Family Therapy—Anxiety and Depression

Children with newly diagnosed diabetes. Hakimi ^26^ conducted an RCT to assess effectiveness of a family-based psychosocial intervention designed to ameliorate the negative psychological impact of diabetes. There were 35 patients with a mean age of 11.5 years. The setting was not reported, but followup time was reported to be 6 weeks, and there were no significant differences in levels of depression or anxiety between groups. The methodological quality of the study was low (1/5 on the Jadad score; unclear concealment of allocation; blinding of outcome assessors).

#### Skills Training—Anxiety and Depression

Children with newly diagnosed diabetes. One RCT by Mitchell ^49^ assessed the effect of a skills training intervention on coping abilities among 32 newly diagnosed patients (mean age 10.7 years). The intervention group received standard multidisciplinary education and support plus a booklet targeted at improving compliance with treatment. The booklet identified problems with adherence and offered basic self-management skills. The standard care group received standard education and support. At the 12-month followup, the intervention group reported significant improvement in anxiety, depression and withdrawal characteristics as measured with the Child Behaviour Checklists. There was no change for the control group. The methodological quality of the study was low (1/5 on the Jadad score; unclear concealment of allocation). Both the intervention and control groups had substantial dropouts over the study period (47 and 53 percent, respectively).

#### Summary of Results—Anxiety and Depression

General population of children with diabetes. One moderate quality RCT (Grey et al. ^21^ ) assessed the effect of a cognitive behavioral therapy intervention on depression in the general population of children with type 1 diabetes (Table 19). Both the intervention and control groups reported reduced depression; however, the difference was not statistically significant.

Table 19 Summary of results of studies assessing the effect of diabetes education on anxiety and depression

Author Year | Intervention | Study design Sample size | Quality | Results
General population of children with diabetes
Grey ^21^ 2000 | Cognitive behavioral therapy | RCT 77 | Moderate | Depression—Both groups reported less depression at 12 mo.; difference between groups was NS
Children with newly diagnosed diabetes
Hakimi ^26^ | Family therapy | RCT 35 | Low | Anxiety—No significant difference between groups at 6 wk. Depression—No significant difference between groups at 6 wk.
Hoff ^30^ 2005 | General diabetes education | RCT 46 | High | Child internalizing problems—(maternal report) IG reported decreased levels at 1 and 6 mo.; no change for CG Child internalizing problems—(paternal report) IG reported no change at 1 and 6 mo.; CG reported decreased levels at 1 mo. but no change at 6 mo.
Mitchell ^49^ 1996 | Skills | RCT 32 | Low | Depression, anxiety and withdrawal—IG reported significant improvement at 12 mo.; no change for CG
Children with poorly controlled diabetes
Cigrang ^13^ 1992 | Cognitive behavioral therapy | RCT (3 arms) 37 | Low | Depression—No significant difference between groups at 3 mo.
Hains ^25^ 2000 | Cognitive behavioral therapy | RCT 15 | Low | Anxiety—No significant difference between groups at 1 mo.

CG = control group; IG = intervention group; NS = not significant

Children with newly diagnosed diabetes. One high-quality RCT (Hoff et al. ^30^ ) reported mixed results of a general diabetes education delivered to parents of children with newly diagnosed diabetes (Table 19). Mothers in the intervention group reported that children had fewer internalizing problems compared to mothers in the control group. Conversely, fathers in the intervention group reported no change in children's internalizing problems. The remaining two studies that focused on children with newly diagnosed diabetes were of low quality. One RCT reported improvement on a composite measure of depression, anxiety and withdrawal for the intervention group; ^49^ the RCT found no difference in anxiety and depression levels between the intervention and control groups. ^26^

Children with poorly controlled diabetes. Two low-quality RCTs found no difference between intervention and control groups on measures of anxiety ^25^ and depression ^13^ in the population of children with poorly controlled diabetes (Table 19).

## Quality of Life

Overall there were four studies that assessed the effect of diabetes education on quality of life (QOL). All examined the general population of children with diabetes.

### General Diabetes Education—Quality of Life

General population of children with diabetes. In an uncontrolled before-and-after study, von Sengbusch et al. ^77^ assessed the impact of a mobile diabetes education service on a group of 107 children living in rural areas in the United States. At both 6- and 12-month followups there was a statistically significant improvement in QOL using the KINDL^®^ quality of life questionnaire. The methodological quality of this study was moderate based on the Thomas assessment tool.

### Cognitive Behavioral Therapy—Quality of Life

General population of children with diabetes. Grey et al. ^21^ randomly assigned 77 adolescents to receive intensive diabetes management as described in the Diabetes Control and Complications Trial or intensive diabetes management plus a behavioral program of coping-skills training intervention. At 10-months post-intervention, the intervention group experienced less negative impact on QOL as measured by the Diabetes Quality of Life: Youth tool. The methodological quality of this study was moderate (2/5 on the Jadad scale; unclear concealment of allocation; blinding of outcome assessors).

### Family Therapy—Quality of Life

General population of children with diabetes. Laffel et al. ^38^ randomly assigned 105 families to a family-focused teamwork intervention, or to standard care (i.e., routine multidisciplinary clinical care). QOL was assessed using the PedsQL, which was administered to both children and parents. At 12-months post-intervention, there was no difference in the QOL scores between the intervention and standard care groups. The methodological quality of this study was assessed as low (2/5 on the Jadad scale; unclear concealment of allocation).

### Skills Training—Quality of Life

General population of children with diabetes. In an uncontrolled before-and-after study by Caravalho and Saylor, ^11^ 56 children and their parents were taught insulin adjustment procedures and received group support and education to improve self-management. QOL was assessed using the Quality of Life Parent Questionnaire (adapted from the Diabetes Quality of Life instrument). QOL scores improved from pre- to post-intervention (12 months) assessment, but the improvement was not statistically significant (p = 0.07). The methodological quality of this study was weak based on the Thomas instrument.

### Summary of Results—Quality of Life

Overall, there was limited evidence for the QOL outcome and the results were mixed (Table 20). One moderate quality RCT (Grey et al. ^21^ ) found that adolescents who received coping skills training along with intensive diabetes management experienced less negative impact on QOL compared with those who received intensive management only. Similarly, the moderate quality uncontrolled before-and-after study by von Sengbusch et al. ^77^ reported a statistically significant improvement in QOL scores at 12 months. The RCT by Laffel et al. ^38^ found no difference in QOL scores between the family therapy group and control group. Caravalho and Saylor ^11^ reported improved scores for parents of children with diabetes, but the change from baseline was not statistically significant.

Table 20 Summary of results of studies assessing the effect of diabetes education on quality of life

Author Year | Intervention | Study design Sample size | Quality | Conclusion
General population of children with diabetes
Caravalho ^11^ 2000 | Skills | Before-after 56 | Low | Parents had improved QOL scores at 12 mo.; difference was NS
Grey ^21^ 2000 | Cognitive behavioral therapy | RCT 77 | Moderate | IG experienced less negative QOL than CG at 10 mo.
Laffel ^38^ 2003 | Family therapy | RCT 105 | Low | No significant differences in QOL between groups at 12 mo.
von Sengbusch ^77^ 2006 | General diabetes education | Before-after 107 | Moderate | Significant improvement in QOL scores at 6 mo. and 12 mo.

CG = control group, IG = intervention group; NS = not significant

## School Performance

Overall there were two RCTs that assessed the effect of diabetes education on school performance. One examined the general population of children with diabetes and one focused on children with newly diagnosed diabetes (Table 21).

Table 21 Summary of results of studies assessing the effect of diabetes education on school performance

Author Year | Intervention | Study design Sample size | Quality | Conclusion
General population of children with diabetes
Pichert ^59^ 1994b | Diabetes camp | RCT 84 | Moderate | No significant difference in number of school absences between groups at 8 mo.
Children with newly diagnosed diabetes
Dougherty ^18^ 1999 | General diabetes education | RCT 63 | Moderate | No significant difference in sick days between groups at 24 mo.

### General Diabetes Education—School Performance

Children with newly diagnosed diabetes. Dougherty et al. ^18^ randomly assigned 63 newly diagnosed patients to a 24-month home-based diabetes education program or to a traditional hospitalization and outpatient followup. Treatment differences between the groups consisted of duration of initial hospital stay, timing of initial teaching, and the nature and extent of subsequent nursing followup. During the course of the 2-year study, there was no difference in absences from school between the groups (28.3±36.4 days for the hospital-based group and 29.7±28.7 days for the home-based group. The methodological quality of this study was moderate (2/5 on the Jadad scale; unclear allocation of concealment; blinding of outcome assessors).

### Diabetes Camp—School Performance

General population of children with diabetes. Pichert et al. ^59^ randomly assigned 84 patients to either a control group, which participated in two 45-minute sessions where traditional teaching methods were employed to review 9 guidelines for sick-day management; or, to an intervention group, which participated in two 45-minute sessions using a video tape and discussion to review nine guidelines for sick-day management. At 8-month followup there was no significant difference between groups for the number of sick days in the past 10 weeks. The methodological quality of this study was moderate (2/5 on the Jadad scale; unclear allocation of concealment; blinding of outcome assessors).

### Summary of Results—School Performance

Overall, there was limited evidence relating to this outcome (Table 21). In the two studies assessing this outcome, diabetes education programs did not have a significant effect on school absence or sick days.