# 2 Methods

In this chapter, we document a prospectively designed protocol that the University of Alberta/Capital Health Evidence-based Practice Center (UA/CH EPC) used to develop this evidence report. To accomplish the tasks as directed, a core research team at the UA/CH EPC was assembled. In consultation with the Agency for Healthcare Research and Quality (AHRQ) Task Order Officer (TOO) and the American Academy of Pediatrics (AAP) representatives, a Technical Expert Panel (TEP) was invited to provide high-level content and methodological expertise in the development of the report (Appendix A).

In developing a framework for the report, the five key questions were considered parts of a larger question about the effectiveness of diabetes education for children and their families for various short- and long-term physical (metabolic) and psychosocial outcomes (Figure 1).

Figure 1. Analytical framework for evidence report on the effectiveness of diabetes education

## Literature Search and Retrieval

We systematically searched the following electronic resources: MEDLINE^®^ Ovid, Ovid MEDLINE^®^ In-Process & Other Non-Indexed Citations, Cochrane Central Register of Controlled Trials (contains the Cochrane Metabolic and Endocrine Disorders Group, which hand searches journals pertinent to its content area and adds relevant trials to the registry), Cochrane Database of Systematic Reviews (CDSR), Database of Abstracts of Reviews of Effects (DARE), HealthSTAR, EMBASE, CINAHL^®^, ERIC, PsycINFO^®^, CINAHL Plus with Full Text (EBSCO), Science Citation Index Expanded^®^ and Social Sciences Citation Index^®^ (both via ISI Web of Knowledge^SM^), PubMed^®^, LILACS (Latin American and Caribbean Health Science Literature), Proquest^®^ Dissertations & Theses, CRISP (Computer Retrieval of Information on Scientific Projects), National Library of Medicine (NLM) Gateway, OCLC ProceedingsFirst and PapersFirst, and trial registries such as The National Research Register, ClinicalTrials.gov, and Current Controlled Trials. We also searched the websites of relevant professional associations and research groups including the National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK), American Association of Diabetes Educators, European Association for the Study of Diabetes (EASD), and TRIP Database (Turning Research Into Practice) for additional unpublished controlled trials and reports. The reference lists of relevant reviews and included studies were reviewed, and authors of included studies were contacted as required (e.g., to clarify the source of population in cases of multiple publications or to seek additional data). This search was limited to English language studies published after 1982. The search was not limited by study design or publication status. It is considered current up to March 2, 2007.

For the search strategies, a combination of subject headings and keywords were developed for each electronic resource using the following terms: diabetes mellitus, type 1, IDDM, diabetes mellitus, DM, insulin dependent diabetes mellitus, early diabetes mellitus, juvenile diabetes mellitus, labile diabetes mellitus, autoimmune diabetes mellitus, sudden onset diabetes mellitus, diabetic ketoacidosis, DKA, ketoacidosis, patient education, health education, patient care management, self-care, self-regulation, self-monitoring, self-management, home care services, school health services, diabetic diet, diet therapy, nutrition therapy, nutrition education, diabetes education, health behavior, attitude to health, counseling, adolescent psychology, child psychology, behavior therapy, cognitive therapy, family therapy, outcome assessment (health care), attitude to health, program, intervention, inform, teach, train, learn, educate, effect, impact, knowledge, skill, cope, video, game, telephone, self-help groups, treatment program, hypoglycemia, blood glucose, self-monitoring, self-monitoring blood glucose, glycosylated hemoglobin A, hemoglobin A, HbA1c, metabolic control, glycemic control, self-efficacy, program evaluation, treatment outcome, health behavior, problem solving, compliance, improve, quality of life, hospitalization, admission, and service utilization. Appendix B documents the exact search strategy for each database.

## Study Selection

Our inclusion and exclusion criteria were developed in consultation with the TEP and are documented in Table 2. In consultation with the TEP, we made a post hoc decision to exclude studies that had 10 or fewer study participants.

Table 2 Inclusion and exclusion criteria for studies assessing the effectiveness of diabetes education for children and their families

Study design | Include: Any study design Exclude: Studies with ≤10 participants
Participants | Children aged 0 to 18 years with type 1 diabetes mellitus or families of children with type 1 diabetes mellitus
Interventions | Diabetes education programs that incorporate at least one of the following content areas: (1) diabetes disease process and treatment options; (2) nutritional management; (3) physical activity; (4) monitoring blood glucose, urine ketones (when appropriate), and using the results to improve control; (5) utilizing medications; (6) preventing, detecting, and treating acute complications; (7) preventing (through risk reduction behavior), detecting, and treating chronic complications; (8) goal setting to promote health and problem solving for daily living; (9) psychosocial adjustment
Outcomes | Include: Metabolic control (HbA1c), hospitalization, ED utilization, short-term complications (e.g., diabetic ketoacidosis, episodes of hypoglycemia), long-term complications (retinal, renal, cardiovascular, neurological), quality of life, school attendance and performance, self-confidence in ability to cope with disease, psychosocial outcomes Exclude: lifestyle outcomes (e.g., smoking, use of recreational drugs, participation in extracurricular activities)

ED = emergency department

We used a two-step process for article screening. First, two reviewers independently screened the titles and abstracts (when available) to determine if an article met the general inclusion criteria. Each article was rated as “include,” “exclude,” or “unclear.” The full text of all articles classified as “include” or “unclear” was retrieved for formal review. Next, two reviewers independently assessed each study using a standard inclusion/exclusion form (Appendix C). Disagreements were resolved by consensus or third party adjudication.

## Assessment of Methodological Quality

The methodological quality of randomized controlled trials (RCTs) and controlled clinical trials (CCTs) was assessed independently by two reviewers using two quality assessment instruments. They were not blinded to authors, setting, or results. First, a five-point scoring system validated by Jadad ^101^ (Appendix C) was used to assess randomization, double blinding, and reporting of withdrawals and dropouts. These components are associated with a risk of bias. Second, allocation concealment, failure of which has been associated with an increase in the potential for selection bias, was assessed as adequate, inadequate, or unclear. ^102,^ ^103^ Decision rules regarding the application of the tools were developed a priori and discrepancies were resolved through discussion between the two reviewers. In addition, the funding source was recorded. ^104^

A post hoc assessment of blinding of outcome assessors was carried out for all RCTs and CCTs. Studies were given credit for this component if they described procedures for blinding outcome assessors to treatment allocation of study participants. Disagreements were resolved through discussion between reviewers.

The methodological quality of all other study designs was assessed independently by two reviewers using the Thomas Quality Assessment Tool for Quantitative Studies ^105^ – ^107^ (Appendix C). The tool aims to provide assessment criteria applicable to any study design and includes 21 items separated into 8 categories: selection bias, study design, confounders, blinding, data collection methods, withdrawals and dropouts, intervention integrity, and analysis. Following completion of the tool, reviewers provide an overall rating of the study (strong/moderate/weak) for each of the first 6 components. Decision rules for the application of the tool were developed a priori through discussions with the lead investigators. Discrepancies were resolved through discussion between the two reviewers.

## Grading the Body of Evidence

To assess the strength of evidence for the key outcomes (HbA1c, short-term complications, knowledge of diabetes, self-management skills, coping with diabetes and quality of life), we used the approach developed by the Grading of Recommendation Assessment, Development, and Evaluation (GRADE) working group. ^108^ – ^110^ This approach assesses the evidence based on five key elements: the strength of the study designs providing the evidence, the quality of the studies, the consistency of the estimates of effect across studies, the precision or degree of certainty surrounding an effect estimate, and the directness of the link between the intervention and outcome measures. We classified the strength of evidence as high, moderate, low, or very low. Decision rules for the application of the GRADE approach were developed a priori, and two reviewers scored each element independently. Differences in assessment were resolved by consensus.

## Data Extraction

Data were extracted using standardized forms and entered into a Microsoft Access database (Microsoft Corp., Redmond, WA) (Appendix C). Data were extracted by one reviewer (AM, CS, ES, or KO) and checked for accuracy and completeness by a second (AM, CS, ES, KO or YL). Extracted data included study characteristics, inclusion/exclusion criteria, and the characteristics of participants, interventions, and outcomes described in Table 2. Reviewers resolved discrepancies in data extraction by consensus or in consultation with a third party.

The following broad categories were used to group studies by outcome: HbA1c, knowledge of diabetes, skills and self-management behaviors, psychosocial outcomes (e.g., coping skills, self-esteem, quality of life), complications (short- and long-term), and health service utilization (e.g., hospitalizations). After reviewing the included studies, we grouped interventions into the following broad categories: general diabetes education (which included education given to both inpatients and outpatients on topics addressing etiology, clinical course, and general management of the disease), skills training (including training in skills related to self management, insulin injections, adherence, and nutrition), cognitive behavioral therapy (including techniques such as problem solving, goal setting, behavior modification, stress management, and coping skills), family systems therapy (including techniques that focus on family communication skills and the role of family interaction in adherence to health regimens), medical nutrition therapy, psychoeducation, physical activity, and diabetes camps. Within the parameters of each outcome and intervention, we also extracted and presented the results by population type: the general population of children with diabetes, children that were newly diagnosed with diabetes, and children who have poor metabolic control. For the purposes of this report, we considered an absolute change in HbA1c of 0.5 percent (e.g. from 9.0 percent to 8.5 percent) to be a clinically important difference.

## Data Analysis

The following data assumptions were made and imputations performed to transform reported data into the form required for analysis for this review. Graph extraction was performed using CorelDRAW^®^9.0 (Corel Corp., Ottawa, Canada). If necessary, means were approximated by medians, and 95 percent empirical confidence intervals were used to calculate approximate standard deviations (SD). Change from baseline data at various time points were used whenever possible for continuous data; however, since correlations between baseline data and endpoint data were never reported, a correlation of 0.5 was assumed ^111^ to calculate the appropriate SD for the change from baseline data. Change from baseline and endpoint data were combined in the same meta-analysis; both figures estimate the difference between treatment groups. ^112^ For multiarm studies, data from similar treatment groups were combined if appropriate.

Quantitative results were meta-analyzed in Review Manager version 4.2.5 (The Cochrane Collaboration, Copenhagen, Denmark). Dichotomous results (e.g., hospitalizations), are reported as relative risks (RR) for individual studies and a pooled result was calculated for those studies that could be combined. For continuous variables measured on the same scale (e.g., HbA1c), mean differences were calculated for individual studies, and the weighted mean difference (WMD) was calculated for the pooled estimate. For continuous variables measured on different scales (e.g., knowledge of diabetes), mean differences were calculated for separate studies and the standardized mean difference (SMD) was calculated for the pooled estimate. All results are reported with 95 percent confidence intervals (95% CI), when possible.

Due to expected differences among studies, we decided a priori to combine results using random effects models. ^113^ Statistical heterogeneity was quantified using the I-squared (I^2^) statistic. ^114^ A value greater than 50 percent was considered to be substantial heterogeneity, and grounds for not presenting the combined results. ^114^

For our primary outcome, HbA1c, we tested visually for publication bias using the funnel plot and quantitatively using the rank correlation test, ^115^ the graphical test, ^116^ and the trim and fill method. ^117^ Publication bias calculations were performed using STATA 7.0 (STATACorp., College Station, TX).

## Peer Review

Eight experts in pediatric endocrinology, diabetes education, or medical nutrition education agreed to act as peer reviewers (Appendix A) and were sent a copy of the draft report. Reviewers had one month in which to provide critical feedback. All comments and authors' replies were submitted to the AHRQ for assessment and approval. The draft report was amended based on reviewers' comments.