# Executive Summary

## Introduction

Currently, type 1 diabetes affects 1 in every 400 to 600 children, and more than 13,000 children are newly diagnosed each year.^1,2^

Type 1 diabetes is managed by insulin replacement and balancing of diet and exercise in order to maintain glycemic control and prevent the occurrence of complications. Glycemic control, which is linked directly to complication rates,^1^ is monitored by the measurement of glycosylated hemoglobin (HbA1c), which reflects the mean blood glucose level over the previous 2 to 3 months. Lowering HbA1c has been associated with a reduction of microvascular complications of diabetes.^3^

In order to effectively manage diabetes, education about components of management such as blood glucose monitoring, insulin replacement, diet, exercise, and problem solving strategies must be delivered to the patient. Education is important both at diagnosis, where there is usually no knowledge base and patient and family are given the basic skills for controlling the disease,^4^ and throughout the patient's lifetime, with ongoing attention to self-management skills, screening and prevention of complications, and to new developments in these areas. Since management of diabetes requires lifestyle changes, it is important that education be delivered to the whole family.

## Key Questions

The American Academy of Pediatrics put forth the following five questions:

1 What is the evidence that diabetes education on day-to-day management of diabetes improves metabolic control (as determined by HbA1c, numbers of diabetes-related hospitalizations, frequency of diabetic ketoacidosis [DKA] and numbers of episodes of hypoglycemia)?
2 What is the evidence that medical nutrition therapy education on day-to-day management of diabetes improves HbA1c values and results in less variability in blood glucose levels?
3 What is the evidence that diabetes education results in improved long-term management of diabetes, including better adherence to recommendations made in clinic and decreased hospitalizations and emergency department (ED) visits for diabetes-related complications?
4 What is the evidence that diabetes education programs improve knowledge about diabetes management?
  a What is the evidence that this knowledge increases the child's self-confidence in his or her ability to handle the disease and has a positive impact on the child's quality of life (QOL) and other psychosocial issues (e.g., school absences, school performance, adherence to a medical regimen)?
  b What is the evidence that this knowledge improves long-term metabolic control (i.e., decreases or prevents diabetes-related complications), as shown in the Diabetes Control and Complications Trial (DCCT) (as measured by retinal, renal, cardiovascular, and neurological evaluations), in children of families who receive these diabetes education or medical nutrition therapy program services compared to children of families who do not receive these services?
5 What is the evidence that training in intensive diabetes management (consistent with DCCT, including blood glucose monitoring at least 4 times a day, 3 or more daily insulin injections or use of an insulin pump and education on when and how to adjust insulin doses) conducted in the practitioner setting yields:
  a Improved metabolic control, (as determined by HbA1c values, numbers of diabetes-related hospitalizations, frequency of DKA and numbers of episodes of hypoglycemia)?
  b A decrease in or prevention of diabetes-related complications (as measured by retinal, renal, cardiovascular, and neurological evaluations), as demonstrated by DCCT?

## Methods

### Literature Search

Search terms were adapted for the following electronic databases: MEDLINE^®^ Ovid, Ovid MEDLINE^®^ In-Process & Other Non-Indexed Citations, Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews (CDSR), Database of Abstracts of Reviews of Effects (DARE), HealthSTAR, EMBASE, CINAHL^®^, ERIC, PsycINFO^®^, CINAHL Plus with Full Text (EBSCO), Science Citation Index Expanded^®^ and Social Sciences Citation Index^®^ (both via ISI Web of Knowledge^SM^), PubMed^®^, LILACS (Latin American and Caribbean Health Science Literature), Proquest^®^ Dissertations & Theses, CRISP (Computer Retrieval of Information on Scientific Projects), National Library of Medicine (NLM) Gateway, OCLC ProceedingsFirst and PapersFirst, and trial registries such as The National Research Register, ClinicalTrials.gov, and Current Controlled Trials. We also searched websites of relevant professional associations, and reference lists of relevant reviews and included studies. Only English-language studies were included.

### Study Selection

Two reviewers independently screened titles and abstracts to determine if an article met general inclusion criteria. The full text of all articles identified as “include” or “unclear” was retrieved for formal review.

Using a priori inclusion criteria, two reviewers independently assessed each full text article using a standard form. Disagreements were resolved by consensus or third-party adjudication.

### Quality Assessment

Two reviewers independently assessed the methodological quality of included studies. The Jadad Scale and Schulz criteria for allocation concealment were used to assess the methodological quality of randomized and nonrandomized controlled clinical trials. In a post hoc assessment, trials were given credit if outcome assessors were blinded to outcomes. The Thomas Quality Assessment Tool for Quantitative Studies was used to assess studies of other designs. In addition, the funding source was recorded.

### Data Extraction

Data were extracted by one reviewer using standardized forms and checked for accuracy and completeness by a second reviewer. Extracted data included inclusion/exclusion criteria, and the characteristics of participants, interventions, and outcomes. Disagreements were resolved by consensus or third-party adjudication.

### Data Analysis

Due to extreme heterogeneity in study designs, interventions, populations, and outcomes, no meta-analyses were performed. Interventions were grouped into nine broad categories: general diabetes education (21 studies), interventions based on cognitive behavioral therapy (24 studies), family therapy (9 studies), skills training (7 studies), and programs delivered at diabetes camps (17 studies), as well as psychoeducation (2 studies) and a physical activity program (1 study). Results are presented first by outcome (e.g. HbA1c), then by intervention, and then by population subgroup (general population, children with newly diagnosed diabetes, or children with poor metabolic control).

## Results

### Included Studies

As a result of the search, 12,756 citations were identified. One hundred articles were included in the review, representing 80 unique primary studies.^5^–^84^ The number of enrolled participants in the studies ranged from 11 to 332 (median = 50 [IQR = 30 to 89]). The mean age of study participants ranged from 2.7 to 16 years.

### Outcomes

HbA1c. 52 studies assessed the effectiveness of diabetes education programs in controlling HbA1c levels (Table 1). Overall, the methodological quality of studies was low, with three RCTs assessed as high quality and nine studies assessed as moderate quality. Thirty-one studies assessed the general population of children with diabetes. Nine studies reported that HbA1c levels decreased significantly following the interventions. The successful interventions fell into the categories of family therapy (n = 3), cognitive behavioral therapy (n = 4), general diabetes education (n = 1), and skills training (n = 1). The one moderate quality RCT examined the addition of a coping skills intervention to intensive diabetes management. Six studies found that HbA1c levels improved significantly for both the intervention and control groups; however, differences between groups were not statistically significant. The remaining 16 studies reported that diabetes education had no significant effect on improving HbA1c levels, thus in the majority of the studies there was no evidence for increase in effectiveness of the educational interventions over the education provided in standard care.

Table 1 Summary table for diabetes education for children with type 1 diabetes

Intervention | Quantity of evidence | Quality of evidence | Results | | | Summary of findings | Strength of evidence
| | | IG improved vs. CG; significant | IG or both IG & CG changed; NS | No change
General population of children with diabetes
HbA1c
General diabetes education | 4 RCT | Low | | 1 | 3 | In general, interventions were not effective; heterogeneity across interventions precluded direct comparisons; some studies assessed content while others looked at mode of delivery (e.g., video game, group vs. individual training) | Low
General diabetes education | 2 B-A | Moderate | 1 | | 1 | | Low
General diabetes education | | | | | | | Low
1 B-A | Low | | 1
1 Cohort | Low | | 1
Cognitive behavioral therapy | 1 RCT | Moderate | 1 | | | Individual studies demonstrated that some cognitive behavioral therapy interventions may be effective (e.g., coping skills training); heterogeneity across interventions precluded direct comparisons | Low
Cognitive behavioral therapy | 8 RCT | Low | 2 | 3 | 3 | Individual studies demonstrated that some cognitive behavioral therapy interventions may be effective (e.g., coping skills training); heterogeneity across interventions precluded direct comparisons | Low
Cognitive behavioral therapy | | | | | | Individual studies demonstrated that some cognitive behavioral therapy interventions may be effective (e.g., coping skills training); heterogeneity across interventions precluded direct comparisons | Low
1 CCT | Low | | 1
1 Cohort | Low | 1
Diabetes camp | 1 RCT | Low | | | 1 | No effect | Moderate
Diabetes camp | 2 CCT | Low | | | 2 | No effect | Moderate
1 B-A | Low | | | 1
Family therapy | 3 RCT | Low | 3 | | | Interventions that focus on family teamwork or support may be effective | Moderate
Physical training | 1 RCT | Low | | | 1 | Insufficient evidence
Skills training | 1 B-A | Low | | | 1 | Mixed effects | Low
1 Cohort | Low | 1
Psychoeducation | 1 RCT | Moderate | | | 1 | Insufficient evidence
Health services utilization
General diabetes education | 1 RCT | Moderate | 1 | | | Individual studies demonstrated that some interventions may be effective; heterogeneity across interventions precluded direct comparisons | Moderate
General diabetes education | 1 RCT | Low | 1 | | | Individual studies demonstrated that some interventions may be effective; heterogeneity across interventions precluded direct comparisons | Moderate
1 B-A | Moderate | 1
Diabetes camp | 1 B-A | Moderate | | 1 | | Insufficient evidence
Short-term complications
General diabetes education | 1 RCT | Moderate | 1 | | | Individual studies demonstrated that some interventions may be effective; heterogeneity across interventions precluded direct comparisons | Low
General diabetes education | 2 B-A | Moderate | 1 | | 1 | Individual studies demonstrated that some interventions may be effective; heterogeneity across interventions precluded direct comparisons | Low
General diabetes education | | | | | | Individual studies demonstrated that some interventions may be effective; heterogeneity across interventions precluded direct comparisons | Low
1 B-A | Low | | 1
1 Cohort | Low | 1
Cognitive behavioral therapy | 2 RCT | Moderate | 1 | | 1 | Mixed effects; 1 RCT reported complication rates decreased; however, rates were still unacceptably high | Low
1 Cohort | Low | 1
Physical training | 1 RCT | Low | | | 1 | Insufficient evidence
Skills training | 1 RCT | Low | 1 | | | Skills training interventions may be effective | Low
1 Cohort | Low | 1
Knowledge
General diabetes education | 3 RCT | Low | 1 | 1 | 1 | Specific interventions may be effective; heterogeneity across interventions and outcome measures precluded direct comparisons | Low
General diabetes education | 1 CCT | Low | 1 | | | Specific interventions may be effective; heterogeneity across interventions and outcome measures precluded direct comparisons | Low
General diabetes education | | | | | | Specific interventions may be effective; heterogeneity across interventions and outcome measures precluded direct comparisons | Low
2 B-A | Moderate | 2
2 B-A | Low | 1 | 1
Cognitive behavioral therapy | 1 RCT | Moderate | | 1 | | Specific interventions may be effective; heterogeneity across interventions precluded direct comparisons | Low
Cognitive behavioral therapy | 2 RCT | Low | 1 | | 1 | Specific interventions may be effective; heterogeneity across interventions precluded direct comparisons | Low
Cognitive behavioral therapy | | | | | | Specific interventions may be effective; heterogeneity across interventions precluded direct comparisons | Low
3 CCT | Low | 1 | 2
1 B-A | Moderate | 1
Diabetes camp | 1 RCT | Moderate | | 1 | | Mixed effects; content of specific interventions varied across studies | Low
Diabetes camp | 2 RCT | Low | 1 | | 1 | Mixed effects; content of specific interventions varied across studies | Low
Diabetes camp | | | | | | Mixed effects; content of specific interventions varied across studies | Low
1 CCT | Low | | | 1
3 B-A | Low | 2 | | 1
Skills training | 1 B-A | Moderate | | 1 | | May be effective; knowledge increased but changes were NS | Low
1 B-A | Low | | 1
Skills
Cognitive behavioral therapy | 1 RCT | Low | | | 1 | Specific interventions may be effective; heterogeneity across interventions precluded direct comparisons | Low
Cognitive behavioral therapy | 1 CCT | Low | 1 | | | Specific interventions may be effective; heterogeneity across interventions precluded direct comparisons | Low
1 B-A | Low | 1
Diabetes camp | 3 RCT | Low | | | 3 | Mixed effects; content of specific interventions varied across studies | Low
Diabetes camp | 1 B-A | Moderate | | | 1 | Mixed effects; content of specific interventions varied across studies | Low
2 B-A | Low | 2
Self-management or regimen adherence
General diabetes education | 3 RCT | Low | 2 | | 1 | Specific interventions may be effective; heterogeneity across interventions precluded direct comparisons | Low
General diabetes education | 1 CCT | Low | 1 | | | Specific interventions may be effective; heterogeneity across interventions precluded direct comparisons | Low
1 B-A | Moderate | | | 1
Cognitive behavioral therapy | 1 RCT | Moderate | 1 | | | Specific interventions may be effective; heterogeneity across interventions precluded direct comparisons | Low
4 RCT | Low | 2 | | 2
Family therapy | 2 RCT | Low | 2 | | | Specific interventions may be effective | Low
Diabetes camp | 2 CCT | Low | | | 2 | No effect | Low
Psychosocial outcomes
General diabetes education | 1 RCT | Low | 1 | | | Specific interventions may be effective improving family support and coping skills | Low
1 B-A | Low | 1
Cognitive behavioral therapy | 3 RCT | Moderate | 2 | 1 | | Specific interventions may be effective in improving family relationships, family support, efficacy, self-perception | Low
Cognitive behavioral therapy | 2 RCT | Low | 2 | | | Specific interventions may be effective in improving family relationships, family support, efficacy, self-perception | Low
Cognitive behavioral therapy | | | | | | Specific interventions may be effective in improving family relationships, family support, efficacy, self-perception | Low
Cognitive behavioral therapy | 3 CCT | Low | 2 | | 1 | Specific interventions may be effective in improving family relationships, family support, efficacy, self-perception | Low
1 Cohort | Low | 1
1 B-A | Moderate | 1
Family therapy | 3 RCT | Low | | 1 | 2 | No effect | Low
Diabetes camp | 2 CCT | Low | 2 | | | Mixed effects; content of specific interventions varied across studies | Low
Diabetes camp | 1 B-A | Moderate | | | 1 | Mixed effects; content of specific interventions varied across studies | Low
3 B-A | Low | 1 | | 2
Skills training | 1 B-A | Low | 1 | | | Insufficient evidence
Quality of life
General diabetes education | 1 B-A | Moderate | 1 | | | Insufficient evidence
Cognitive behavioral therapy | 1 RCT | Moderate | 1 | | | Insufficient evidence
Family therapy | 1 RCT | Low | | 1 | | Insufficient evidence
Skills training | 1 B-A | Low | | 1 | | Insufficient evidence
School performance
Diabetes camp | 1 RCT | Moderate | | 1 | | Insufficient evidence
Children with newly diagnosed diabetes
HbA1c
General diabetes education | 1 RCT | Moderate | 1* | | | Compared inpatient vs. ambulatory delivery of education; mixed effects; interventions were dissimilar | Low
1 Cohort | Moderate | | | 1*
Cognitive behavioral therapy | 1 RCT | Moderate | 1 | | | Specific interventions may be effective (e.g., family-based skills training); the comparison group for one study was ‘no education’ | Low
1 CCT | Low | 1
Family therapy | 2 RCT | Low | | 1* | 1 | Insufficient evidence; 1 study found no difference between inpatient vs. ambulatory delivery of education
Skills training | 1 RCT | Low | | 1 | | Mixed effects | Low
1 Cohort | Moderate | 1
Health service utilization
General diabetes education | 2 Cohort | Moderate | 1 | | 1* | Insufficient evidence; 1 study compared inpatient vs. ambulatory setting; 1 assessed skill level of educator
Cognitive behavioral therapy | 1 CCT | Low | 1 | | | Insufficient evidence
Skills training | 1 Cohort | Moderate | 1 | | | Insufficient evidence
Short-term complications
General diabetes education | 1 RCT | Moderate | | 1* | | Insufficient evidence
Cognitive behavioral therapy | 1 CCT | Low | 1 | | | Insufficient evidence
Skills training | 1 Cohort | Moderate | 1 | | | Insufficient evidence
Knowledge
General diabetes education | 1 RCT | Moderate | | 1* | | Compared inpatient vs. ambulatory delivery of education; knowledge increased in both groups; interventions were dissimilar | Low
2 Cohort | Moderate | | 2*
Self-management and regimen adherence
General diabetes education | 1 RCT | Moderate | 1* | | | Compared inpatient vs. ambulatory delivery of education; mixed effects | Low
1 Cohort | Moderate | | | 1*
Psychosocial outcomes
General diabetes education | 1 RCT | High | 1 | | | No effect | Low
General diabetes education | 1 RCT | Low | | | 1 | No effect | Low
2 Cohort | Moderate | | | 2
Cognitive behavioral therapy | 1 RCT | Low | | | 1 | Insufficient evidence
Family therapy | 3 RCT | Low | | | 3 | No effect | Moderate
Skills training | 1 RCT | Low | 1 | | | Insufficient evidence
School performance
General diabetes education | 1 RCT | Moderate | | 1 | | Insufficient evidence
Children with poor metabolic control
HbA1c
General diabetes education | 1 RCT | High | | | 1 | No effect | Low
1 RCT | Low | | 1
Cognitive behavioral therapy | 4 RCT | Low | | 1 | 3 | In general, interventions were not effective; heterogeneity across interventions precluded direct comparisons | Low
2 CCT | Low | 2
Diabetes camp | 1 B-A | Low | 1 | | | Insufficient evidence
Family therapy | 1 RCT | High | | | 1 | No effect | Low
1 B-A | Low | | | 1
Skills training | 1 RCT | High | | 1 | | No effect | Low
| 1 RCT | Low | | | 1
Psychoeducation | 1 CCT | Low | 1 | | | Insufficient evidence
Health service utilization
General diabetes education | 1 RCT | High | | | 1 | Insufficient evidence
Skills training | 1 RCT | Low | 1 | | | Insufficient evidence
Psychoeducation | 1 CCT | Low | 1 | | | Insufficient evidence
Short-term complications
Diabetes camp | 1 B-A | Low | 1 | | | Insufficient evidence
Knowledge
General diabetes education | 1 RCT | High | | | 1 | Insufficient evidence
Cognitive behavioral therapy | 1 CCT | Low | | 1 | | Insufficient evidence
Diabetes camp | 1 B-A | Low | 1 | | | Insufficient evidence
Self-management and regimen adherence
General diabetes education | 1 RCT | Low | 1 | | | Insufficient evidence
Cognitive behavioral therapy | 2 RCT | Low | | 1 | 1 | No effect | Low
Family therapy | 1 RCT | High | | 1 | | No effect | Low
1 B-A | Low | | | 1
Skills
Diabetes camp | 1 RCT | Low | | | 1 | Insufficient evidence
Psychosocial outcomes
General diabetes education | 1 RCT | High | | | 1 | No effect | Low
1 RCT | Low | | | 1
Cognitive behavioral therapy | 4 RCT | Low | | | 4 | No effect | Low
1 CCT | Low | 1
Family therapy | 1 RCT | High | 1 | | | Mixed effects | Low
1 B-A | Low | | | 1

* Comparing inpatient vs. ambulatory delivery of education intervention; B-A = uncontrolled before-and-after; CCT = controlled clinical trial; CG = control group; IG = intervention group; NS = non significant; RCT = randomized controlled trial

Eight studies assessed diabetes education delivered to children with newly diagnosed diabetes and their families (Table 1). Three studies assessed general diabetes education or family therapy programs that were delivered in an ambulatory setting vs. education delivered during hospitalization. One study reported that the decrease in HbA1c levels was significantly greater for the home-based group vs. the inpatient group, whereas the other two found no significant differences in HbA1c levels between groups. The results of the remaining studies were inconsistent. Three studies reported that cognitive behavioral therapy and skills training interventions resulted in lower HbA1c levels in the intervention group, one study reported that both groups improved, and one study found no difference between the two groups.

Thirteen studies examined HbA1 in children with poorly controlled diabetes (Table 1). Two large, high quality RCTs examining general diabetes education and family therapy reported that the intervention had no significant impact on HbA1c levels. The results of the remaining studies were inconsistent. Four studies reported that HbA1c levels improved following the intervention. Two studies reported an improvement in HbA1c in both intervention and control groups, but there was no significant difference between groups. The remaining five studies reported that diabetes education had no significant effect on HbA1c levels. Due to the heterogeneity across studies and the general low methodological quality, it is difficult to conclude which interventions may have an effect over and above standard care.

Health service utilization. Eleven studies assessed impact of diabetes education on health service utilization (Table 1). Measures of health service utilization included length of stay and hospital or ED admissions for diabetes- and non-diabetes-related complications. Overall, the methodological quality was moderate with one RCT assessed as high quality, six rated as moderate, and four rated as low quality.

The four studies assessing this outcome in the general patient population provide some evidence that diabetes education has an impact on utilization (Table 1). However, there is considerable heterogeneity across studies making it difficult to generalize the results.

Three of the four studies that examined children with newly diagnosed diabetes reported some reduction in health services utilization following the intervention. The results of the three studies that targeted children with poor metabolic control were inconsistent. The high quality RCT reported increased hospital admission rates for both intervention and control groups (i.e., no improvement), while the two low quality trials reported significantly fewer hospital admissions in the intervention group compared to the control group.

Complications. Fifteen studies examined the effect of diabetes education in controlling complications (Table 1). Most studies reported on the incidence of severe hypoglycemia; six reported on the incidence of DKA. Six of the studies were of moderate quality and the other nine were assessed as low quality.

Of the 10 studies that examined the general population of children with diabetes, six found that the intervention had a significant effect. The effective interventions included general diabetes education (n = 2), cognitive behavioral therapy (n = 2), and skills training (n = 2).The remaining studies either showed that there was no improvement or that there was no significant difference between groups for this outcome.

Of three studies assessing this outcome in children with newly diagnosed diabetes, two reported a significant improvement in the intervention group. The third study comparing inpatient vs. outpatient delivery of education found no difference between groups.

The remaining 2 studies assessed children with poor metabolic control and the results both favored the interventions (general diabetes education and diabetes camp).

Knowledge. Thirty studies assessed the effectiveness of diabetes education in improving knowledge. Most studies (n = 20) were assessed as low quality, however, 10 were evaluated as moderate and one RCT as high quality (Table 1). Twenty-four studies examined the general population of children with diabetes. Interventions included general diabetes education (n = 8), cognitive behavioral therapy (n = 6), diabetes camps (n = 7) and skills training (n = 2). Two before-after studies of moderate quality studies reported gains in knowledge after a cognitive behavioral therapy and general diabetes education intervention; however, three other moderate quality before-after studies did not find a significant change following the intervention. The results of the remaining studies were also inconsistent: five reported statistically significant increases in knowledge; two reported found the interventions to be effective in subgroups of the study population; six reported knowledge gains that were not statistically significant or were not retained over the long-term.

Three moderate quality studies compared inpatient vs. ambulatory education in children with newly diagnosed diabetes. All three studies reported increases in knowledge levels for both groups, but differences between groups were not statistically significant. It should be noted that the interventions and outcome measures among studies were different from one another, so results may not be generalizable.

Three studies assessed knowledge among children with poor metabolic control. One high quality RCT did not find a significant change in knowledge for either group. One before-after study reported significant increases in knowledge following a diabetes camp, and one CCT reported significantly higher knowledge levels over the short-term but these gains were not sustained over the long-term.

Skills. Nine studies assessed the effect of diabetes education on the development of diabetes management skills, including self-monitoring of blood glucose (SMBG), nutrition and diet-related skills, and urine testing (Table 1). In the general population of children with diabetes, four studies (2 cognitive behavioral therapy^48^ and 2 camp interventions) found gains in these skills, while four reported no significant change in skills following the intervention.

In the population of children with poor metabolic control, one RCT conducted at diabetes camp found no significant difference between intervention and control groups in SMBG.

Self-management/adherence. Twenty-one studies assessed self management and regimen adherence (Table 1). Of these, fourteen focused on the general population of children with diabetes. One moderate quality and seven low quality studies reported a significant improvement in self-management in the intervention group. Successful interventions included general diabetes education (n = 2), cognitive behavioral therapy (n = 3) and family therapy (n = 2). The remaining studies did not show a significant change.

One study assessed this outcome among children who were newly diagnosed with diabetes and found no significant change. Five studies focused on children with poor metabolic control. One RCT found a significant effect on self-management in blood testing and adherence; the remaining studies found no significant change.

Psychosocial outcomes. Thirty-nine studies examined one or more psychosocial outcomes, including family or social relationships, family or social support, social skills, coping, self-perception, self-efficacy, stress, depression and anxiety (Table 1). Diabetes education was effective in improving several psychosocial outcomes; however, the methodological quality of the studies was generally low and there was considerable heterogeneity across interventions, time points, and measures used.

Quality of life. Two studies found that cognitive behavioral therapy and general diabetes training intervention improved quality of life in the intervention group (Table 1). The remaining two studies that examined this outcome reported that the education interventions had no significant effect.

School performance. There was limited evidence relating to this outcome (Table 1). In the two studies assessing this outcome, diabetes education programs did not have a significant effect on school absence or sick days.

## Discussion

Key Question 1. The results of this review do not indicate that any specific educational intervention improves day-to-day management of metabolic control as determined by HbA1c. More intensive interventions such as cognitive behavioral therapy and family therapy appear to have a small benefit. Studies set in diabetes camps do not show any clear improvement in diabetes control. Diabetes education appears to be effective in decreasing health care utilization, and this effect appears to be associated with education that is intense, provided by specialists, and multidisciplinary teams, and involves some form of psychotherapy or psychosocial focus.

Results were unclear in the area of diabetes-related short-term complications. Most studies did not have high enough rates of DKA to show significant differences. Studies reporting on hypoglycemia covered the spectrum of possible outcomes. A possible explanation for this may be that hypoglycemia has so many potential causes. For example, an intervention may target nocturnal hypoglycemia, but not physical activity-related hypoglycemia. It is also possible that both standard care and standard diabetes education effectively reduce the incidence of hypoglycemia, making it difficult to demonstrate differences among types of educational interventions.

It has been hypothesized that changes in HbA1c may be mediated by changes in knowledge, skills, attitudes and/or behavior. In the 16 studies that examined the association between knowledge and short-term metabolic control the results were inconsistent. It appears that an increase in knowledge is not sufficient to bring about behavior change that improves metabolic control. Likewise, in the 24 studies that measured both psychosocial outcomes and HbA1c, the four studies that measured quality of life and HbA1c, the two studies that measured skills and HbA1c, and the 18 studies that measured adherence and HbA1c, there was little coherence across these outcomes.

Key Question 2. There is no clear evidence on whether medical nutrition therapy education does or does not improve diabetes control. We identified only one uncontrolled before-and-after study that specifically assessed medical nutrition therapy education as the intervention for children attending a diabetes camp. There were several studies that described a nutritional component or module as part of their intervention and reported improved nutritional knowledge or behavior after the intervention; however, this did not correlate with a lowering of HbA1c. Several other studies showed no significant changes in HbA1c or regimen adherence. Further research is needed to answer this question.

Key Question 3. There were no data to answer the question about what, if any, educational interventions improve long-term control and reduce long-term diabetes-related complications. Long-term followup in diabetes is considered 5 to 10 years. Only three studies followed participants for more than 2 years.

Key Question 4. A small number of studies reported that cognitive behavioral therapy or general diabetes education had an effect on knowledge scores in favor of the intervention. However, in the majority of studies that assessed this outcome, there was no difference in knowledge scores between those who received the intervention vs. those who received education that was part of their standard diabetes care. Therefore, no clear recommendation can be made on types of education, beyond standard care, that may improve knowledge. There was also no particular intervention that showed a consistent positive effect of diabetes education on psychosocial outcomes, including quality of life and school performance. We were unable to assess whether improved knowledge had an effect on long- term metabolic control because none of the included studies followed participants beyond 2 years.

Key Question 5. Three studies contributed information to the key question on training in intensive diabetes management in the practitioner setting. All three studies reported improved metabolic control after initiation of the intensive treatment which persisted up to 1 year later. The results of the two studies that examined refinements to the education provided suggest that educational interventions may support the effects of intensive diabetes management in reducing HbA1c levels. In terms of short-term acute complications, the studies showed mixed results with one group reporting an unacceptably high level of severe hypoglycemia suggesting that further educational interventions may need to be explored.

### Future Research Opportunities

Recommendations for further research include:

- Appropriately powered RCTs are needed to assess cognitive behavioral therapy, family therapy, motivational interviewing and frequency of contact with health care professionals on HbA1c and short-term complications, especially in the population of children with poorly controlled diabetes
- RCTs should specify the components of education that is part of standard care and followup. A survey of standard diabetes education programs so that researchers are aware of the diversity of standard care would be a useful addition to the literature.
- Additional research is needed in the area of medical nutrition therapy education.
- Future studies assessing the effect of educational strategies on quality of life should use a standard, validated outcome measure.
- Five- to ten-year followup will help to assess the effect of education on long-term complications of diabetes.
- RCTs and CCTs should blind outcome assessors to the intervention and should report allocation concealment.
- Additional research is needed to examine the aspects of education that improve outcomes associated with intensive diabetes management.

## Conclusions

Due to the heterogeneity of reported diabetes education interventions that are delivered to children with type 1 diabetes and their families, outcome measures, and duration of followup, there is insufficient evidence to recommend a particular education intervention to improve metabolic control, reduce short-term acute complications, or improve quality of life.