# Acknowledgments

We are grateful to members of the technical expert panel, Dr. Denis Daneman (University of Toronto), Alison Evert (University of Washington Medical Center), Dr. Jeff Johnson (University of Alberta), Dr. Richard Justman (United HealthCare), Dr. Lori Laffel (Joslin Diabetes Center), Dr. Gabriela Ramirez (Nemours Children's Clinic), Dr. Janet Silverstein (University of Florida), Linda Walsh (American Academy of Pediatrics), Caryn Davidson (American Academy of Pediatrics) and Stephanie Chang (Agency for Healthcare Research and Quality), who provided direction for the scope and content of the review.

We are grateful to Karalee Ratzlaff for collecting potentially relevant studies, Dr. Nina Buscemi for providing feedback on the draft of this report, and Ken Bond for editing the report.