# List of Acronyms

Acronym | Definition
3TC | lamivodine
ABC/EFV/ddI | abacavir/efavirenz/didanosine
ACEI | angiotensin-converting enzyme inhibitors
ACS | acute chest syndrome
AHRQ | Agency for Healthcare Research and Quality
ALT | alanine transferase
AML | acute myelogenous leukemia
ANC | absolute neutrophil count
ARV | antiretroviral
ASA | acetylsalicylic acid
AST | aspartate transaminase
AUC | area under the curve
BM | bone marrow
BMT | bone marrow transplant
BS/B-thal | hemoglobin S beta-thalassemia
Bu | busulfan
BUN | blood urea nitrogen
CA | cancer
CAR | Central African Republic Haplotype
CBT | cognitive behavioral therapy
CCNU | lomustine
CCT | clinically controlled trial
CERHR | Center for the Evaluation of Risks to Human Reproduction
CI | confidence interval
CLL | chronic lymphocytic leukemia
CML | chronic myelogenous leukemia
CMV | cytomegalovirus
CNS | central nervous system
CrCl | creatinine clearance
CSSCD | Cooperative Study of Sickle Cell Disease
d4t | didehydrodeoxythymidine
ddI | didanosine
DH | day hospital
DNA | deoxyribonucleic acid
dz | disease
ED | emergency department
EFV | efavirenz
EFW | estimated fetal weight
eGFR | estimated globular filtration rate
EPC | Evidence-based Practice Center
ER | emergency room
ET | essential thrombocythemia
FDA | Food and Drug Administration
f/u | follow-up
GI | gastrointestinal
GMP | Granual membrane protien
Hb | hemoglobin
Hb F | fetal hemoglobin
HIV | human immunodeficiency virus
HPRT | hypoxanthine phosphoribosyl transferase
HR | hazard ratio
HTN | hypertension
HU | hydroxyurea
HUG KIDS | pediatric hydroxyurea safety trial
HUSOFT | The Hydroxyurea Safety and Organ Toxicity trial
IBW | isobutyramide
IDV | indinavir
IFN | Interferon
IMF | idiopathic myelofibrosis
IR | index of rigidity
IV | intravenous
JHU | Johns Hopkins University
LACA | left anterior cerebral artery
LMCA | left main coronary artery
LOS | length of stay
LPCA | left posterior cerebral artery
MCV | mean corpuscular volume
MDS | myelodysplastic syndromes
MeSH | medical subject heading
MF | myelofibrosis
MPD | myeloproliferative disorders
MRIs | magnetic resonance imaging
MSH | Multicenter Study of Hydroxyurea for Sickle Cell Anemia
MTD | maximum tolerated dose
NA | not applicable
NEJM | New England Journal of Medicine
NHLBI | National Heart, Lung, and Blood Institute
NIEHS | National Institute of Environmental Health Sciences
NIH | National Institutes of Health
NR | not reported
NA | not applicable
NS | not specified
NTP | National Toxicology Program
OCP | oral contraceptive pill
OMAR | Office of Medical Applications of Research
OR | odds ratio
PBMC | peripheral blood mononuclear cells
PDF | portable document format
PHTN | pulmonary hypertension
PI | pipobraman
plt | platelet
PP | pre/post
preg | pregnancy
PV | polycythemia vera
PVSG | Polycythemia Vera Study Group
QOD | 4 times per day
RACA | right anterior cerebral artery
RBC | red blood cells
RCT | randomized controlled trial
RDS | respiratory distress syndrome
RMCA | right main cerebral artery
RPCA | right posterior cerebral artery
RR | relative risk
S β+ thal | sickle β+ thalassemia
S β^0^ thal | sickle β^0^ thalassemia
S α+ thal | sickle α+ thalassemia
S/O | hemoglobin SO Arab
SA | substance abuse
SC | sickle-hemoglobin C disease
SCA | sickle cell anemia
SCD | sickle cell disease
SD | standard deviation
SEM | standard error of the mean
SS | sickle Hemoglobin SS Disease
SWiTCH | Stroke With Transfusions Changing to Hydroxyurea
TCD | transcranial Doppler
TIA | transient ischemic attack
trans | Transfusion
UGTIA | uridine diphosphoglucuronate glycuronosyltransferase 1A
ULN | upper limit of normal
ULT | upper limit
VOC | vaso-occlusive crisis
WBC | white blood cells
WHO | World Health Organization
ZDV | Zidovudine