# References and Included Studies*

1 Platt OS, Brambilla DJ, Rosse WF, et al. Mortality in sickle cell disease. Life expectancy and risk factors for early death. N Engl J Med. 1994;330(23):1639-44. [pmid: 7993409].
2 U.S. Preventive Services Task Force. Screening for Hemoglobinopathies U.S. Preventive Sercies Task Force, Guidelines from Guide to Clinical Preventive Services. second. 1996 Williams and Wilkens. 1996.
3 McClish DK, Penberthy LT, Bovbjerg VE, et al. Health related quality of life in sickle cell patients: the PiSCES project. Health Qual Life Outcomes. 2005;3:50. [pmid: 16129027]. [pmcid: 1253526].
4 Shapiro BS, Benjamin LJ, Payne R, et al. Sickle cell-related pain: perceptions of medical practitioners. J Pain Symptom Management. 1997;14:168-174.
5 Gaston M, Rosse WF. The cooperative study of sickle cell disease: review of study design and objectives. Am J Pediatr Hematol Oncol. 1982;4(2):197-201. [pmid: 7114401].
6 Platt OS, Thorington BD, Brambilla DJ, et al. Pain in sickle cell disease. Rates and risk factors. N Engl J Med. 1991;325(1):11-6. [pmid: 1710777].
7 Powars DR, Chan LS, Hiti A, et al. Outcome of sickle cell anemia: a 4-decade observational study of 1056 patients. Medicine (Baltimore). 2005;84(6):363-76. [pmid: 16267411].
8 Vichinsky EP, Neumayr LD, Earles AN, et al. Causes and outcomes of the acute chest syndrome in sickle cell disease. National Acute Chest Syndrome Study Group. N Engl J Med. 2000;342(25):1855-65. [pmid: 10861320].
9 Castro O, Brambilla DJ, Thorington B, et al. The acute chest syndrome in sickle cell disease: incidence and risk factors. The Cooperative Study of Sickle Cell Disease. Blood. 1994;84(2):643-9. [pmid: 7517723].
10 Eckman JR. Leg ulcers in sickle cell disease. Hematol Oncol Clin North Am. 1996;10(6):1333-44. [pmid: 8956020].
11 Quinn CT, Rogers ZR, Buchanan GR. Survival of children with sickle cell disease. Blood. 2004;103(11):4023-7. [pmid: 14764527]. [pmcid: 1828870].
12 Kirkham FJ. Therapy insight: stroke risk and its management in patients with sickle cell disease. Nat Clin Pract Neurol 2007;3(5).
13 Dressler WFC, Sterin R. Uber den Hydroxylharnstoff. Jusutus Liebig's Ann Chem Pharm. 1869;150:242-252.
14 Stevens MR. Hydroxyurea: An overview. J Biol Regul Homeostatic Agents. 1999;13(3):172-175.
15 Food and Drug Adminidstation. Med watch. http://www.fda.gov/medwatch/safety/2006/safety06.htm#Hydrea.
16 Krakoff IH, Brown NC, Reichard P. Inhibition of ribonucleoside diphosphate reductase by hydroxyurea. Cancer Res. 1968;28(8):1559-65. [pmid: 4876978].
17 Dover GJ, Charache S. Hydroxyurea induction of fetal hemoglobin synthesis in sickle-cell disease. Semin Oncol. 1992;19(3 Suppl 9):61-6.
18 Cokic VP, Smith RD, Beleslin-Cokic BB, et al. Hydroxyurea induces fetal hemoglobin by the nitric oxide-dependent activation of soluble guanylyl cyclase. J Clin Invest. 2003;111(2):231-9. [pmid: 12531879]. [pmcid: 151872].
19 Ho JA, Pickens CV, Gamcsik MP, et al. In vitro induction of fetal hemoglobin in human erythroid progenitor cells. Exp Hematol. 2003;31(7):586-91. [pmid: 12842703].
20 http://www.bms.com/cgi-bin/anybin.pl?sql=PI_SEQ=72. 2006.
21 Charache S, Terrin ML, Moore RD, et al. Effect of hydroxyurea on the frequency of painful crises in sickle cell anemia. Investigators of the Multicenter Study of Hydroxyurea in Sickle Cell Anemia. N Engl J Med. 1995;332(20):1317-22. [pmid: 7715639].
22 Moore RD, Charache S, Terrin ML, et al. Cost-effectiveness of hydroxyurea in sickle cell anemia. Investigators of the Multicenter Study of Hydroxyurea in Sickle Cell Anemia. Am J Hematol. 2000;64(1):26-31. [pmid: 10815784].
23 The Management of Sickle Cell Disease, 4th. NIH Publication No. 02-2117 2002.
24 Stafford RS, Furberg CD, Finkelstein SN, et al. Impact of clinical trial results on national trends in alpha-blocker prescribing, 1996-2002. JAMA. 2004;291(1):54-62. [pmid: 14709576].
25 Cabana MD, Rand CS, Powe NR, et al. Why don't physicians follow clinical practice guidelines? A framework for improvement. JAMA. 1999;282(15):1458-65. [pmid: 10535437].
26 Center for the Evaluation of Risks to Human Reporoduction. Http://Cerhr.Niehs.Nih.Gov/?
27 Berlin JA. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350(9072):185-6.
28 WHO Collaborating Center for International Drug Monitorin. Http://Www.Who-Umc.Org/DynPage.Aspx?Id=22682.
29 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
30 Normand SL, Sykora K, Li P, et al. Readers guide to critical appraisal of cohort studies: 3. Analytical strategies to reduce confounding. BMJ. 2005;330(7498):1021-3. [pmid: 15860831]. [pmcid: 557157].
31 Mamdani M, Sykora K, Li P, et al. Reader's guide to critical appraisal of cohort studies: 2. Assessing potential for confounding. BMJ. 2005;330(7497):960-2. [pmid: 15845982]. [pmcid: 556348].
32 Rochon PA, Gurwitz JH, Sykora K, et al. Reader's guide to critical appraisal of cohort studies: 1. Role and design. BMJ. 2005;330(7496):895-7. [pmid: 15831878]. [pmcid: 556167].
33 Lincoln TM and Reif W. How much do sample characteristics affect the effect size? An investigation of studies testing the treatment effects for social phobia. J Anxiety Disord 2004;18(4).
34 Tobin GA, Begley CM. Methodological rigour within a qualitative framework. J Adv Nurs. 2004;48(4):388-96. [pmid: 15500533].
35 Horsburgh D. Evaluation of qualitative research. J Clin Nurs. 2003;12(2):307-12. [pmid: 12603565].
36 Ratanawongsa N, Thomas PA, Marinopoulos SS et al. and Reliability of Methods for Evaluating Continuing Medical Education: A Systematic Review. Acad Med in press.
37 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295]. [pmcid: 428525].
38 Jones J. K. Determining causation from case reports. In: Pharmacoepidemiology 4th ED. Brian Strom (Ed) 2005;John Wiley and Sons, West Sussex, England.
39 Charache S, Barton FB, Moore RD, et al. Hydroxyurea and sickle cell anemia. Clinical utility of a myelosuppressive “switching” agent. The Multicenter Study of Hydroxyurea in Sickle Cell Anemia. Medicine (Baltimore). 1996;75(6):300-26. [pmid: 8982148].
40 Steinberg MH, Lu ZH, Barton FB, et al. Fetal hemoglobin in sickle cell anemia: determinants of response to hydroxyurea. Multicenter Study of Hydroxyurea. Blood. 1997;89(3):1078-88. [pmid: 9028341].
41 Hackney AC, Hezier W, Gulledge TP, et al. Effects of hydroxyurea administration on the body weight, body composition and exercise performance of patients with sickle-cell anaemia. Clin Sci (Lond). 1997;92(5):481-6. [pmid: 9176021].
42 Ballas SK, Barton FB, Waclawiw MA, et al. Hydroxyurea and sickle cell anemia: effect on quality of life. Health Qual Life Outcomes. 2006;4:59. [pmid: 16942629]. [pmcid: 1569824].
43 Steinberg MH, Barton F, Castro O, et al. Effect of hydroxyurea on mortality and morbidity in adult sickle cell anemia: risks and benefits up to 9 years of treatment. JAMA. 2003;289(13):1645-51. [pmid: 12672732].
44 Ferster A, Vermylen C, Cornu G, et al. Hydroxyurea for treatment of severe sickle cell anemia: a pediatric clinical trial. Blood. 1996;88(6):1960-4. [pmid: 8822914].
45 el-Hazmi MA, Warsy AS, al-Momen A, et al. Hydroxyurea for the treatment of sickle cell disease. Acta Haematol. 1992;88(4):170-4. [pmid: 1292305].
46 Charache S, Dover GJ, Moore RD, et al. Hydroxyurea: effects on hemoglobin F production in patients with sickle cell anemia. Blood. 1992;79(10):2555-65. [pmid: 1375104].
47 Khayat AS, Antunes LM, Guimaraes AC, et al. Cytotoxic and genotoxic monitoring of sickle cell anaemia patients treated with hydroxyurea. Clin Exp Med. 2006;6(1):33-7. [pmid: 16550342].
48 de Montalembert M, Brousse V, Elie C, et al. Long-term hydroxyurea treatment in children with sickle cell disease: tolerance and clinical outcomes. Haematologica. 2006;91(1):125-8. [pmid: 16434381].
49 McKie KT, Hanevold CD, Hernandez C, et al. Prevalence, prevention, and treatment of microalbuminuria and proteinuria in children with sickle cell disease. J Pediatr Hematol Oncol. 2007;29(3):140-4. [pmid: 17356390].
50 Svarch E, Machin S, Nieves RM, et al. Hydroxyurea treatment in children with sickle cell anemia in Central America and the Caribbean countries. Pediatr Blood Cancer. 2006;47(1):111-2. [pmid: 16550531].
51 Bakanay SM, Dainer E, Clair B, et al. Mortality in sickle cell patients on hydroxyurea therapy. Blood. 2005;105(2):545-7. [pmid: 15454485].
52 Ferguson RP, Arun A, Carter C, et al. Hydroxyurea treatment of sickle cell anemia in hospital-based practices. Am J Hematol. 2002;70(4):326-8. [pmid: 12214583].
53 Schultz WH, Ware RE. Malignancy in patients with sickle cell disease. Am J Hematol. 2003;74(4):249-53. [pmid: 14635205].
54 Gergen PJ, Macri CJ, Murrillo S. The need for sickle cell screening among pediatric latino immigrants. Arch Pediatr Adolesc Med. 2002;156(7):729.
55 de Montalembert M, Begue P, Bernaudin F, et al. Preliminary report of a toxicity study of hydroxyurea in sickle cell disease. French Study Group on Sickle Cell Disease. Arch Dis Child. 1999;81(5):437-9. [pmid: 10519721]. [pmcid: 1718114].
56 Harrod VL, Howard TA, Zimmerman SA, et al. Quantitative analysis of Howell-Jolly bodies in children with sickle cell disease. Exp Hematol. 2007;35(2):179-83. [pmid: 17258066].
57 Hanft VN, Fruchtman SR, Pickens CV, et al. Acquired DNA mutations associated with in vivo hydroxyurea exposure. Blood. 2000;95(11):3589-93. [pmid: 10828048].
58 Ferster A, Tahriri P, Vermylen C, et al. Five years of experience with hydroxyurea in children and young adults with sickle cell disease. Blood. 2001;97(11):3628-32. [pmid: 11369660].
59 Santos A, Pinheiro V, Anjos C, et al. Scintigraphic follow-up of the effects of therapy with hydroxyurea on splenic function in patients with sickle cell disease. Eur J Nucl Med Mol Imaging. 2002;29(4):536-41. [pmid: 11914893].
60 Wang WC, Wynn LW, Rogers ZR, et al. A two-year pilot trial of hydroxyurea in very young children with sickle-cell anemia. J Pediatr. 2001;139(6):790-6. [pmid: 11743503].
61 Cummins O, Anie KA. A comparison of the outcome of cognitive behaviour therapy and hydroxyurea in sickle cell disease. Psychol Health Med. 2003;8(2):199-204.
62 Kratovil T, Bulas D, Driscoll MC, et al. Hydroxyurea therapy lowers TCD velocities in children with sickle cell disease. Pediatr Blood Cancer. 2006;47(7):894-900. [pmid: 16526051].
63 Zimmerman SA, Schultz WH, Burgett S et al. Hydroxyurea therapy lowers transcranial doppler flow velocities in children with sickle cell anemia. Blood 2007.
64 Olivieri NF, Vichinsky EP. Hydroxyurea in children with sickle cell disease: impact on splenic function and compliance with therapy. J Pediatr Hematol Oncol. 1998;20(1):26-31. [pmid: 9482409].
65 Hankins JS, Helton KJ, McCarville MB et al. Preservation of spleen and brain function in children with sickle cell anemia treated with hydroxyurea. Pediatr Blood Cancer 2007.
66 Chaine B, Neonato MG, Girot R, et al. Cutaneous adverse reactions to hydroxyurea in patients with sickle cell disease. Arch Dermatol. 2001;137(4):467-70. [pmid: 11295927].
67 Ware RE, Zimmerman SA, Sylvestre PB, et al. Prevention of secondary stroke and resolution of transfusional iron overload in children with sickle cell anemia using hydroxyurea and phlebotomy. J Pediatr. 2004;145(3):346-52. [pmid: 15343189].
68 Kinney TR, Helms RW, O'Branski EE, et al. Safety of hydroxyurea in children with sickle cell anemia: results of the HUG-KIDS study, a phase I/II trial. Pediatric Hydroxyurea Group. Blood. 1999;94(5):1550-4. [pmid: 10477679].
69 Loukopoulos D, Voskaridou E, Stamoulakatou A, et al. Hydroxyurea therapy in thalassemia. Ann N Y Acad Sci. 1998;850:120-8. [pmid: 9668534].
70 Al-Jam'a AH, Al-Dabbous IA. Hydroxyurea in sickle cell disease patients from Eastern Saudi Arabia. Saudi Med J. 2002;23(3):277-81. [pmid: 11938415].
71 Rigano P, Rodgers GP, Renda D, et al. Clinical and hematological responses to hydroxyurea in Sicilian patients with Hb S/beta-thalassemia. Hemoglobin. 2001;25(1):9-17. [pmid: 11300353].
72 Hankins JS, Ware RE, Rogers ZR, et al. Long-term hydroxyurea therapy for infants with sickle cell anemia: the HUSOFT extension study. Blood. 2005;106(7):2269-75. [pmid: 16172253]. [pmcid: 1895275].
73 Ware RE, Eggleston B, Redding-Lallinger R, et al. Predictors of fetal hemoglobin response in children with sickle cell anemia receiving hydroxyurea therapy. Blood. 2002;99(1):10-4. [pmid: 11756146].
74 Loukopoulos D, Voskaridou E, Kalotychou V, et al. Reduction of the clinical severity of sickle cell/beta-thalassemia with hydroxyurea: the experience of a single center in Greece. Blood Cells Mol Dis. 2000;26(5):453-66. [pmid: 11112383].
75 Maier-Redelsperger M, de Montalembert M, Flahault A, et al. Fetal hemoglobin and F-cell responses to long-term hydroxyurea treatment in young sickle cell patients. The French Study Group on Sickle Cell Disease. Blood. 1998;91(12):4472-9. [pmid: 9616141].
76 de Montalembert M, Belloy M, Bernaudin F, et al. Three-year follow-up of hydroxyurea treatment in severely ill children with sickle cell disease. The French Study Group on Sickle Cell Disease. J Pediatr Hematol Oncol. 1997;19(4):313-8. [pmid: 9256830].
77 Scott JP, Hillery CA, Brown ER, et al. Hydroxyurea therapy in children severely affected with sickle cell disease. J Pediatr. 1996;128(6):820-8. [pmid: 8648542].
78 Voskaridou E, Kalotychou V, Loukopoulos D. Clinical and laboratory effects of long-term administration of hydroxyurea to patients with sickle-cell/beta-thalassaemia. Br J Haematol. 1995;89(3):479-84. [pmid: 7537527].
79 Ataga KI, Moore CG, Jones S, et al. Pulmonary hypertension in patients with sickle cell disease: a longitudinal study. Br J Haematol. 2006;134(1):109-15. [pmid: 16803576].
80 Vicari P, Barretto de Mello A, Figueiredo MS. Effects of hydroxyurea in a population of Brazilian patients with sickle cell anemia. Am J Hematol. 2005;78(3):243-4. [pmid: 15726590].
81 Zimmerman SA, Schultz WH, Davis JS, et al. Sustained long-term hematologic efficacy of hydroxyurea at maximum tolerated dose in children with sickle cell disease. Blood. 2004;103(6):2039-45. [pmid: 14630791].
82 Gulbis B, Haberman D, Dufour D, et al. Hydroxyurea for sickle cell disease in children and for prevention of cerebrovascular events: the Belgian experience. Blood. 2005;105(7):2685-90. [pmid: 15604217].
83 Scothorn DJ, Price C, Schwartz D, et al. Risk of recurrent stroke in children with sickle cell disease receiving blood transfusion therapy for at least five years after initial stroke. J Pediatr. 2002;140(3):348-54. [pmid: 11953734].
84 Wilimas J, Goff JR, Anderson HR Jr, et al. Efficacy of transfusion therapy for one to two years in patients with sickle cell disease and cerebrovascular accidents. J Pediatr. 1980;96(2):205-8. [pmid: 7351580].
85 Athanassiou G, Moutzouri A, Kourakli A, et al. Effect of hydroxyurea on the deformability of the red blood cell membrane in patients with sickle cell anemia. Clin Hemorheol Microcirc. 2006;35(12):291-5. [pmid: 16899945].
86 Iyamu EW, Cecil R, Parkin L, et al. Modulation of erythrocyte arginase activity in sickle cell disease patients during hydroxyurea therapy. Br J Haematol. 2005;131(3):389-94. [pmid: 16225659].
87 Nahavandi M, Tavakkoli F, Wyche MQ, et al. Nitric oxide and cyclic GMP levels in sickle cell patients receiving hydroxyurea. Br J Haematol. 2002;119(3):855-7. [pmid: 12437671].
88 Lapoumeroulie C, Benkerrou M, Odievre MH, et al. Decreased plasma endothelin-1 levels in children with sickle cell disease treated with hydroxyurea. Haematologica. 2005;90(3):401-3. [pmid: 15749673].
89 Tavakkoli F, Nahavandi M, Wyche MQ, et al. Plasma levels of TNF-alpha in sickle cell patients receiving hydroxyurea. Hematology. 2004;9(1):61-4. [pmid: 14965870].
90 Heeney MM, Howard TA, Zimmerman SA, et al. UGT1A promoter polymorphisms influence bilirubin response to hydroxyurea therapy in sickle cell anemia. J Lab Clin Med. 2003;141(4):279-82. [pmid: 12677174].
91 Nahavandi M, Tavakkoli F, Wyche MQ, et al. Arterialization of venous blood for differentiation of sickle cell subjects in vaso-occlusive crisis. Hematology. 2003;8(6):421-428. [pmid: 14668039].
92 Teixeira SM, Cortellazzi LC, Grotto HZ. Effect of hydroxyurea on G gamma chain fetal hemoglobin synthesis by sickle-cell disease patients. Braz J Med Biol Res. 2003;36(10):1289-92. [pmid: 14502358].
93 Zumberg MS, Reddy S, Boyette RL, et al. Hydroxyurea therapy for sickle cell disease in community-based practices: a survey of Florida and North Carolina hematologists/oncologists. Am J Hematol. 2005;79(2):107-13. [pmid: 15929107].
94 Thauvin-Robinet C, Maingueneau C, Robert E, et al. Exposure to hydroxyurea during pregnancy: a case series. Leukemia. 2001;15(8):1309-11. [pmid: 11480579].
95 Dilek I, Topcu N, Demir C, et al. Hematological malignancy and pregnancy: A single-institution experience of 21 cases. Clin Lab Haematol. 2006;28(3):170-176. [pmid: 16706933].
96 Moschovi M, Psychou F, Menegas D, et al. Hodgkin's disease in a child with sickle cell disease treated with hydroxyurea. Pediatr Hematol Oncol. 2001;18(6):371-6. [pmid: 11554231].
97 Kattamis A, Lagona E, Orfanou I, et al. Clinical response and adverse events in young patients with sickle cell disease treated with hydroxyurea. Pediatr Hematol Oncol. 2004;21(4):335-42. [pmid: 15205096].
98 3Ferster A, Sariban E, Meuleman N. Malignancies in sickle cell disease patients treated with hydroxyurea. Br J Haematol. 2003;123(2):368-9. [pmid: 14531924].
99 Al-Jam'a AH, Al-Dabbous IA, Al-Khatti AA, et al. Are we underestimating the leukemogenic risk of hydroxyurea. Saudi Med J. 2002;23(11):1411-3. [pmid: 12506308].
100 Wilson S. Acute leukemia in a patient with sickle-cell anemia treated with hydroxyurea. Ann Intern Med. 2000;133(11):925-6.
101 Rauch A, Borromeo M, Ghafoor A et al. Leukemogenesis of hydroxyurea in the treatment of sickle cell anemia [abstract]. Blood 1999;94 (Suppl 1).
102 Rutschmann OT, Opravil M, Iten A, et al. Didanosine plus stavudine with or without hydroxyurea in HIV-1-infected patients: 1 year follow-up. Antiviral Ther. 1998;3(SUPPL 4):65-67.
103 Kiladjian JJ, Rain JD, Bernard JF et al. Long-term incidence of hematological evolution in three French prospective studies of hydroxyurea and pipobroman in polycythemia vera and essential thrombocythemia. Semin Thromb Hemost 2006.
104 Frank I, Bosch RJ, Fiscus S, et al. Activity, safety, and immunological effects of hydroxyurea added to didanosine in antiretroviral-naive and experienced HIV type 1-infected subjects: a randomized, placebo-controlled trial, ACTG 307. AIDS Res Hum Retroviruses. 2004;20(9):916-26. [pmid: 15597521].
105 Najean Y, Rain JD, Dresch C, et al. Risk of leukaemia, carcinoma, and myelofibrosis in 32P- or chemotherapy-treated patients with polycythaemia vera: A prospective analysis of 682 cases. LEUK LYMPHOMA. 1996;22(SUPPL. 1):111-119. [pmid: 8951781].
106 Gangat N, Wolanskyj AP, McClure RF, et al. Risk stratification for survival and leukemic transformation in essential thrombocythemia: A single institutional study of 605 patients. Leukemia. 2007;21(2):270-276. [pmid: 17170720].
107 Bernasconi P, Boni M, Cavigliano PM, et al. Acute myeloid leukemia (AML) having evolved from essential thrombocythemia (ET): distinctive chromosome abnormalities in patients treated with pipobroman or hydroxyurea. Leukemia. 2002;16(10):2078-83. [pmid: 12357360].
108 Seminari E, Lisziewicz J, Tinelli C, et al. Hydroxyurea toxicity combined with didanosine (ddI) in HIV-1-seropositive asymptomatic individuals. Int J Clin Pharmacol Ther. 1999;37(10):514-518. [pmid: 10543320].
109 Rutschmann OT, Opravil M, Iten A et al. A placebo-controlled trial of didanosine plus stavudine, with and without hydroxyurea, for HIV infection. The Swiss HIV Cohort Study. AIDS 1998.
110 Rutschmann OT, Vernazza PL, Bucher HC, et al. Long-term hydroxyurea in combination with didanosine and stavudine for the treatment of HIV-1 infection. AIDS. 2000;14(14):2145-2151. [pmid: 11061656].
111 Swindells S, Cohen CJ, Berger DS, et al. Abacavir, efavirenz, didanosine, with or without hydroxyurea, in HIV-infected adults failing initial nucleoside/protease inhibitor-containing regimens. BMC Infect Dis. 2005;5(-):13p. [pmid: 15769289]. [pmcid: 1274271].
112 Hehlmann R, Heimpel H, Hasford J, et al. Randomized comparison of busulfan and hydroxyurea in chronic myelogenous leukemia: Prolongation of survival by hydroxyurea. Blood. 1993;82(2):398-407. [pmid: 8329700].
113 Hehlmann R, Heimpel H, Hasford J, et al. Randomized comparison of interferon-alpha with busulfan and hydroxyurea in chronic myelogenous leukemia. The German CML Study Group. Blood. 1994;84(12):4064-77. [pmid: 7994025].
114 Hehlmann R, Berger U, Pfirrmann M, et al. Randomized comparison of interferon alpha and hydroxyurea with hydroxyurea monotherapy in chronic myeloid leukemia (CML-study II): prolongation of survival by the combination of interferon alpha and hydroxyurea. Leukemia. 2003;17(8):1529-37. [pmid: 12886239].
115 Randomized study on hydroxyurea alone versus hydroxyurea combined with low-dose interferon-alpha 2b for chronic myeloid leukemia. The Benelux CML Study Group. Blood 1998;91(8):2713–21.
116 Broustet A, Reiffers J, Marit G, et al. Hydroxyurea versus interferon alfa-2b in chronic myelogenous leukaemia: preliminary results of an open French multicentre randomized study. Eur J Cancer. 1991;27(Suppl 4):S18-21.
117 Yin CC, Cortes J, Barkoh B, et al. t(3;21)(q26;q22) in myeloid leukemia: an aggressive syndrome of blast transformation associated with hydroxyurea or antimetabolite therapy. Cancer. 2006;106(8):1730-8. [pmid: 16532439].
118 Vassallo C, Passamonti F, Merante S, et al. Mucocutaneous changes during long-term therapy with hydroxyurea in chronic myeloid leukaemia. Clin Exp Dermatol. 2001;26(2):141-148. [pmid: 11298103].
119 Urabe A, Mizoguchi H, Takaku F. Hydroxyurea in the therapy of chronic myelogenous leukemia. ACTA HAEMATOL JPN. 1990;53(8):1589-1593.
120 Duletic-Nacinovic A, Labar B, Sever-Prebilic M. Busulfan versus hydroxyurea in therapy of chronic myelogenous leukemia in 1(st) chronic phase. Cancer Res Ther Control. 2000;10(4):251-261.
121 Stephens RL, Vaughn C, Lane M, et al. Adriamycin and cyclophosphamide versus hydroxyurea in advanced prostatic cancer. A randomized Southwest Oncology Group study. Cancer. 1984;53(3):406-10. [pmid: 6362815].
122 Loening SA, Scott WW, deKernion J, et al. A comparison of hydroxyurea, methyl-chloroethyl-cyclohexy-nitrosourea and cyclophosphamide in patients with advanced carcinoma of the prostate. J Urol. 1981;125(6):812-6. [pmid: 7017170].
123 Najean Y, Rain JD. Treatment of polycythemia vera: the use of hydroxyurea and pipobroman in 292 patients under the age of 65 years. Blood. 1997;90(9):3370-7. [pmid: 9345019].
124 Finazzi G, Caruso V, Marchioli R, et al. Acute leukemia in polycythemia vera: an analysis of 1638 patients enrolled in a prospective observational study. Blood. 2005;105(7):2664-70. [pmid: 15585653].
125 Kaplan ME, Mack K, Goldberg JD, et al. Long-term management of polycythemia vera with hydroxyurea: a progress report. Semin Hematol. 1986;23(3):167-71.
126 Fruchtman SM, Mack K, Kaplan ME, et al. From efficacy to safety: A Polycythemia Vera Study Group report on hydroxyurea in patients with polycythemia vera. SEMIN HEMATOL. 1997;34(1):17-23. [pmid: 9025158].
127 Donovan PB, Kaplan ME, Goldberg JD, et al. Treatment of polycythemia vera with hydroxyurea. Am J Hematol. 1984;17(4):329-34. [pmid: 6496458].
128 West WO. Hydroxyurea in the treatment of polycythemia vera: a prospective study of 100 patients over a 20-year period. South Med J. 1987;80(3):323-7. [pmid: 3824016].
129 Cortelazzo S, Finazzi G, Ruggeri M, et al. Hydroxyurea for patients with essential thrombocythemia and a high risk of thrombosis. NEW ENGL J MED. 1995;332(17):1132-1136. [pmid: 7700286].
130 Finazzi G, Ruggeri M, Rodeghiero F, et al. Second malignancies in patients with essential thrombocythaemia treated with busulphan and hydroxyurea: long-term follow-up of a randomized clinical trial. Br J Haematol. 2000;110(3):577-83. [pmid: 10997967].
131 Harrison CN, Campbell PJ, Buck G, et al. Hydroxyurea compared with anagrelide in high-risk essential thrombocythemia. N Engl J Med. 2005;353(1):33-45. [pmid: 16000354].
132 Sterkers Y, Preudhomme C, Lai JL, et al. Acute myeloid leukemia and myelodysplastic syndromes following essential thrombocythemia treated with hydroxyurea: high proportion of cases with 17p deletion. Blood. 1998;91(2):616-22. [pmid: 9427717].
133 Chim CS, Kwong YL, Lie AK, et al. Long-term outcome of 231 patients with essential thrombocythemia: prognostic factors for thrombosis, bleeding, myelofibrosis, and leukemia. Arch Intern Med. 2005;165(22):2651-8. [pmid: 16344424].
134 Nielsen I, Hasselbalch HC. Acute leukemia and myelodysplasia in patients with a Philadelphia chromosome negative chronic myeloproliferative disorder treated with hydroxyurea alone or with hydroxyurea after busulphan. Am J Hematol. 2003;74(1):26-31. [pmid: 12949887].
135 Weinfeld A, Swolin B, Westin J. Acute leukaemia after hydroxyurea therapy in polycythaemia vera and allied disorders: prospective study of efficacy and leukaemogenicity with therapeutic implications. Eur J Haematol. 1994;52(3):134-9. [pmid: 8168592].
136 Randi ML, Ruzzon E, Tezza F, et al. Toxicity and side effects of hydroxyurea used for primary thrombocythemia. Platelets. 2005;16(34):181-4. [pmid: 16011962].
137 Randi ML, Ruzzon E, Luzzatto G, et al. Safety profile of hydroxyurea in the treatment of patients with Philadelphia-negative chronic myeloproliferative disorders. Haematologica. 2005;90(2):261-2. [pmid: 15710584].
138 Hankins J, Hinds P, Day S, et al. Therapy preference and decision-making among patients with severe sickle cell anemia and their families&. Pediatr Blood Cancer. 2007;48(7):705-10. [pmid: 16732581].
139 Treadwell MJ, Law AW, Sung J, et al. Barriers to adherence of deferoxamine usage in sickle cell disease. Pediatr Blood Cancer. 2005;44(5):500-7. [pmid: 15602707].
140 Wurst KE, Sleath BL. Physician knowledge and adherence to prescribing antibiotic prophylaxis for sickle cell disease. Int J Qual Health Care. 2004;16(3):245-51. [pmid: 15150156].
141 Sox CM, Cooper WO, Koepsell TD, et al. Provision of pneumococcal prophylaxis for publicly insured children with sickle cell disease. JAMA. 2003;290(8):1057-61. [pmid: 12941678].
142 Elliott V, Morgan S, Day S, et al. Parental health beliefs and compliance with prophylactic penicillin administration in children with sickle cell disease. J Pediatr Hematol Oncol. 2001;23(2):112-6. [pmid: 11216702].
143 Teach SJ, Lillis KA, Grossi M. Compliance with penicillin prophylaxis in patients with sickle cell disease. Arch Pediatr Adolesc Med. 1998;152(3):274-8. [pmid: 9529466].
144 Jensen SA, Elkin DT, Hilker K, et al. Caregiver knowledge and adherence in children with sickle cell disease: Knowing is not doing. J Clin Psychol Med Settings. 2005;12(4):333-337.
145 Armstrong FD, Pegelow CH, Gonzalez JC, et al. Impact of children's sickle cell history on nurse and physician ratings of pain and medication decisions. J Pediatr Psychol. 1992;17(5):651-64. [pmid: 1359048].
146 Pence L, Valrie CR, Gil KM, et al. Optimism Predicting Daily Pain Medication Use in Adolescents with Sickle Cell Disease. J Pain Symptom Manage. 2007;33(3):302-309. [pmid: 17349499].
147 Telfair J, Haque A, Etienne M, et al. Rural/urban differences in access to and utilization of services among people in Alabama with sickle cell disease. Public Health Rep. 2003;118(1):27-36. [pmid: 12604762]. [pmcid: 1497507].
148 Logan DE, Radcliffe J, Smith-Whitley K. Parent factors and adolescent sickle cell disease: associations with patterns of health service use. J Pediatr Psychol. 2002;27(5):475-84. [pmid: 12058011].
149 Wojciechowski EA, Hurtig A, Dorn L. A natural history study of adolescents and young adults with sickle cell disease as they transfer to adult care: a need for case management services. J Pediatr Nurs. 2002;17(1):18-27. [pmid: 11891491].
150 Haque A, Telfair J. Socioeconomic distress and health status: the urban-rural dichotomy of services utilization for people with sickle cell disorder in North Carolina. J Rural Health. 2000;16(1):43-55. [pmid: 10916314].
151 Barakat LP, Smith-Whitley K, Ohene-Frempong K. Treatment adherence in children with sickle cell disease: Disease-related risk and psychosocial resistance factors. J Clin Psychol Med Settings. 2002;9(3):201-209.
152 Belgrave FZ, Lewis DM. The role of social support in compliance and other health behaviors for African Americans with chronic illnesses. J Health Soc Policy. 1994;5(34):55-68. [pmid: 10138763].
153 Pack-Mabien A, Labbe E, Herbert D, et al. Nurses' attitudes and practices in sickle cell pain management. Appl Nurs Res. 2001;14(4):187-92. [pmid: 11699021].
154 Murray N, May A. Painful crises in sickle cell disease—patients' perspectives. BMJ. 1988;297(6646):452-4. [pmid: 3139140]. [pmcid: 1833896].
155 Labbe E, Herbert D, Haynes J. Physicians' attitude and practices in sickle cell disease pain management. J Palliat Care. 2005;21(4):246-51. [pmid: 16483093].
156 Telfair J, Myers J, Drezner S. Does race influence the provision of care to persons with sickle cell disease? Perceptions of multidisciplinary providers. J Health Care Poor Underserved. 1998;9(2):184-95. [pmid: 10073202].
157 Vichinsky E, Rust D, Lubin B. A possible disparity between standard of care and delivery of care in sickle cell disease, as assessed from sickle cell centers. Int J Pediatr Hematol Oncol. 1999;6(3):189-197.
158 Walters MC, Patience M, Leisenring W, et al. Barriers to bone marrow transplantation for sickle cell anemia. Biol Blood Marrow Transplant. 1996;2(2):100-4. [pmid: 9118298].
159 Booker MJ, Blethyn KL, Wright CJ, et al. Pain management in sickle cell disease. Chronic Illn. 2006;2(1):39-50. [pmid: 17175681].
160 Rouse CM. Paradigms and politics: shaping health care access for sickle cell patients through the discursive regimes of biomedicine. Cult Med Psychiatry. 2004;28(3):369-99. [pmid: 15600118].
161 Maxwell K, Streetly A, Bevan D. Experiences of hospital care and treatment seeking for pain from sickle cell disease: qualitative study. BMJ. 1999;318(7198):1585-90. [pmid: 10364116]. [pmcid: 28137].
162 Tucker C, Spencer J, Dowling PT, et al. Developing a community for patients with sickle cell anemia at Harbor-UCLA. Emphasis Nurs. 1995;5(1):19-27. [pmid: 7705269].
163 Alleyne J, Thomas VJ. The management of sickle cell crisis pain as experienced by patients and their carers. J Adv Nurs. 1994;19(4):725-32. [pmid: 8021394].
164 Shelley B, Kramer KD, Nash KB. Sickle cell mutual assistance groups and the health services delivery system. J Health Soc Policy. 1994;5(34):243-59. [pmid: 10138761].
165 Strickland OL, Jackson G, Gilead M, et al. Use of focus groups for pain and quality of life assessment in adults with sickle cell disease. J Natl Black Nurses Assoc. 2001;12(2):36-43. [pmid: 11902019].
166 Harris A, Parker N, Barker C. Adults with sickle cell disease: Psychological impact and experience of hospital services. Psychol Health Med. 1998;3(2):171-179.
167 Butler DJ, Beltran LR. Functions of an adult sickle cell group: education, task orientation, and support. Health Soc Work. 1993;18(1):49-56. [pmid: 8444372].
168 Waters J, Thomas V. Pain from sickle-cell crisis. Nurs Times. 1995;91(16):29-31.
169 Witherspoon D, Drotar D. Correlates of adherence to prophylactic penicillin therapy in children with sickle cell disease. Child Health Care. 2006;35(4):281-296.
170 Pejaver RK, Ahmed FE, Al Hifzi I. Compliance to penicillin prophylaxis amongst Saudi children with sickle cell disease. J IR COLL PHYS SURG. 1997;26(4):268-270.
171 Chestnut DE. Perceptions of ethnic and cultural factors in the delivery of services in the treatment of sickle cell disease. J Health Soc Policy. 1994;5(34):215-42. [pmid: 10138760].
172 Mitchell MB, Lambright WD, Breish R et al. Meeting the challenge of managing vaso-occlusive crisis. J Healthc Qual 2002;24(3):4–8, 56.
173 Co JP, Johnson KB, Duggan AK, et al. Does a clinical pathway improve the quality of care for sickle cell anemia?. Jt Comm J Qual Saf. 2003;29(4):181-90. [pmid: 12698808].
174 Jamison C, Brown HN. A special treatment program for patients with sickle cell crisis. Nurs Econ. 2002;20(3):126-32. [pmid: 12077963].
175 Cooper GS, Armitage KB, Ashar B, et al. Design and implementation of an inpatient disease management program. Am J Manag Care. 2000;6(7):793-801. [pmid: 11067376].
176 Benjamin LJ, Swinson GI, Nagel RL. Sickle cell anemia day hospital: an approach for the management of uncomplicated painful crises. Blood. 2000;95(4):1130-6. [pmid: 10666181].
177 Day J. An audit of pain management in acute sickle cell crisis. Nurs Times. 1997;93(2):33-4.
178 Brookoff D, Polomano R. Treating sickle cell pain like cancer pain. Ann Intern Med. 1992;116(5):364-8. [pmid: 1736768].
179 Fertleman CR, Gallagher A, Rossiter MA. Evaluation of fast track admission policy for children with sickle cell crises: questionnaire survey of parents' preferences. BMJ. 1997;315(7109):650. [pmid: 9310567]. [pmcid: 2127460].
180 Treadwell MJ, Franck LS, Vichinsky E. Using quality improvement strategies to enhance pediatric pain assessment. Int J Qual Health Care. 2002;14(1):39-47. [pmid: 11871628].
181 Treadwell MJ, Weissman L. Improving adherence with deferoxamine regimens for patients receiving chronic transfusion therapy. Semin Hematol. 2001;38(1 Suppl 1):77-84. [pmid: 11206966].
182 Berkovitch M, Papadouris D, Shaw D, et al. Trying to improve compliance with prophylactic penicillin therapy in children with sickle cell disease. Br J Clin Pharmacol. 1998;45(6):605-7. [pmid: 9663818]. [pmcid: 1873646].
183 Ketchen B, Hazzard A, Lassiter S, et al. STARBRIGHT World: A pilot study of a home-based sickle cell psychoeducational intervention. Child Health Care. 2006;35(4):321-338.
184 Patik M, Phillips L, Kladny B, et al. Structured telephone-based outreach using nonmedical personnel can improve adherence to comprehensive care in families of children with sickle cell disease. Am J Hematol. 2006;81(6):462-4. [pmid: 16680738].
185 Woods KF, Johnson JA, Kutlar A, et al. Sickle cell disease telemedicine network for rural outreach. J Telemed Telecare. 2000;6(5):285-90. [pmid: 11070590].
186 Smith LA, Oyeku SO, Homer C, et al. Sickle cell disease: a question of equity and quality. Pediatrics. 2006;117(5):1763-70. [pmid: 16651336].
187 Sumoza A, de Bisotti R, Sumoza D, et al. Hydroxyurea (HU) for prevention of recurrent stroke in sickle cell anemia (SCA). Am J Hematol. 2002;71(3):161-5. [pmid: 12410569].
188 Yan JH, Ataga K, Kaul S, et al. The influence of renal function on hydroxyurea pharmacokinetics in adults with sickle cell disease. J Clin Pharmacol. 2005;45(4):434-45. [pmid: 15778424].
189 Havlir DV, Gilbert PB, Bennett K, et al. Effects of treatment intensification with hydroxyurea in HIV-infected patients with virologic suppression. AIDS. 2001;15(11):1379-88. [pmid: 11504959].
190 Seminari E, Lisziewicz J, Tinelli C, et al. Hydroxyurea toxicity combined with didanosine (ddl) in HIV-1-seropositive asymptomatic individuals. Int J Clin Pharmacol Ther. 1999;37(10):514-8. [pmid: 10543320].
191 Bloch MT, Smith DE, Quan D et al. The role of hydroxyurea in enhancing the virologic control achieved through structured treatment interruption in primary HIV infection: final results from a randomized clinical trial (Pulse). J Acquir Immune Defic Syndr 2006.
192 Rutschmann OT, Opravil M, Iten A, et al. A placebo-controlled trial of didanosine plus stavudine, with and without hydroxyurea, for HIV infection. AIDS. 1998;12(8):F71-F77. [pmid: 9631134].
193 Rutschmann OT, Opravil M, Iten A, et al. Didanosine plus stavudine with or without hydroxyurea in HIV-1-infected patients: 1 year follow-up. Swiss HIV Cohort Study. Antivir Ther. 1998;3(Suppl 4):65-7. [pmid: 10723515].
194 Rutschmann OT, Vernazza PL, Bucher HC, et al. Long-term hydroxyurea in combination with didanosine and stavudine for the treatment of HIV-1 infection. Swiss HIV Cohort Study. AIDS. 2000;14(14):2145-51. [pmid: 11061656].
195 Hehlmann R, Heimpel H, Hasford J, et al. Randomized comparison of busulfan and hydroxyurea in chronic myelogenous leukemia: prolongation of survival by hydroxyurea. The German CML Study Group. Blood. 1993;82(2):398-407. [pmid: 8329700].
196 Mavrogianni D, Viniou N, Michali E, et al. Leukemogenic risk of hydroxyurea therapy as a single agent in polycythemia vera and essential thrombocythemia: N- and K-ras mutations and microsatellite instability in chromosomes 5 and 7 in 69 patients. Int J Hematol. 2002;75(4):394-400. [pmid: 12041671].

### * Included references not cited in the report (primarily case reports and case studies

Abhyankar D, Shende C, Saikia T, et al. Hydroxyurea induced leg ulcers. J Assoc Physicians India. 2000;48(9):926-7. [pmid: 11198798].
Akinci B, Yesil S, Atabey A, et al. Hydroxyurea associated leg ulcer succesfully treated with hyperbaric oxygen in a diabetic patient. Exp Clin Endocrinol Diabetes. 2007;115(2):143-5. [pmid: 17318777].
Aragane Y, Okamoto T, Yajima A, et al. Hydroxyurea-induced foot ulcer successfully treated with a topical basic fibroblast growth factor product. Br J Dermatol. 2003;148(3):599-600. [pmid: 12653764].
Aste N, Fumo G, Biggio P. Multiple squamous epitheliomas during long-term treatment with hydroxyurea. J Eur Acad Dermatol Venereol. 2001;15(1):89-90. [pmid: 11451342].
Au WY, Hung KN, Loong F, et al. Patients presenting with CNS lesions. Case 3. Sequential myeloproliferative disease and glioblastoma multiforme in a renal transplant recipient. J Clin Oncol. 2003;21(21):4062-3. [pmid: 14581430].
Azagury M, Martelli JM, Morcelet M, et al. Development of hairy cell leukemia in a patient treated with cytoreductive agents for essential thrombocythemia. Leuk Lymphoma. 2003;44(6):1067-9. [pmid: 12854912].
Bacher U, Haferlach T, Kern W, et al. A case of chronic myeloproliferative syndrome followed by precursor T-cell acute lymphoblastic leukemia. Cancer Genet Cytogenet. 2007;175(1):52-56. [pmid: 17498558].
Bader U, Banyai M, Boni R, et al. Leg ulcers in patients with myeloproliferative disorders: Disease- or treatment-related?. Dermatology. 2000;200(1):45-48. [pmid: 10681614].
Bahadoran P, Castanet J, Lacour JP, et al. Pseudo-dermatomyositis induced by long-term hydroxyurea therapy: report of two cases. Br J Dermatol. 96;134(6):1161-3.
Barnhill RL, Wiles JC. Malignant melanoma associated with multiple therapies for psoriasis. J Am Acad Dermatol. 89;21(1):148-50.
Batlle M, Fernandez-Aviles F, Ribera JM, et al. Acute promyelocytic leukemia in a patient with idiopathic myelofibrosis. Leukemia. 99;13(3):492-4.
Beeson M, Antwi EK, Vesely DL. Hydroxyurea-induced hypogonadism. Endocrinologist. 99;9(5):389-390.
Bergin PS, Gale AN. Complex neuromuscular disorder in a patient with chronic myeloid leukaemia. Postgrad Med J. 93;69(810):312-4.
Berkahn LC, Nelson J, Ockelford PA, et al. Transformation of essential thrombocythaemia to T cell acute lymphoblastic leukaemia. Leuk Lymphoma. 96;20(34):347-9.
Best PJ, Petitt RM. Multiple skin cancers associated with hydroxyurea therapy. Mayo Clin Proc. 98;73(10):961-3.
Best PJ, Daoud MS, Pittelkow MR, et al. Hydroxyurea-induced leg ulceration in 14 patients. Ann Intern Med. 98;128(1):29-32.
Beylot-Barry M, Vergier B, Beylot C, et al. Multiple squamous cell carcinomas after prolonged treatment with hydroxyurea. EUR J DERMATOL. 95;5(3):227-230.
Blonk MC, Ossenkoppele GJ. Hydroxyurea as a cause of drug fever in chronic myeloid leukaemia. Neth J Med. 88;32(56):240-2.
Bohn J, Hansen JP, Menne T. Ulcerative lichen planus-like dermatitis due to long-term hydroxyurea therapy. J Eur Acad Dermatol Venereol. 98;10(2):187-9.
Bouldouyre MA, Avril MF, Gaulier A, et al. Association of cutaneous side-effects of hydroxyurea and neuroendocrine carcinoma. Eur J Dermatol. 2005;15(4):268-70. [pmid: 16048756].
Braester A, Quitt M. Hydroxyurea as a cause of drug fever. Acta Haematol. 2000;104(1):50-51. [pmid: 11111124].
Brazzelli V, Bellani E, Barbagallo T, et al. Melanonychia due to hydroxyurea therapy. G Ital Dermatol Venereol. 2005;140(6):723-726.
Brincker H, Christensen BE. Acute mucocutaneous toxicity following high-dose hydroxyurea. Cancer Chemother Pharmacol. 93;32(6):496-7.
Budny AM, Forman M. Cutaneous ulceration secondary to hydroxyurea treatment. J Am Podiatr Med Assoc. 2006;96(6):525-7. [pmid: 17114610].
Burns DA, Sarkany I, Gaylarde P. Effects of hydroxyurea therapy on normal skin: a case report. Clin Exp Dermatol. 80;5(4):447-9.
Cacciola E, Cacciola RR, Guglielmo P, et al. Acute myeloid leukemia occurring in a patient with polycythemia vera in treatment with hydroxyurea. Haematologica. 99;84(8):755-6.
Cakir B, Sucak G, Haznedar R. Longitudinal pigmented nail bands during hydroxyurea therapy. Int J Dermatol. 97;36(3):236-7.
Callot-Mellot C, Bodemer C, Chosidow O, et al. Cutaneous carcinoma during long-term hydroxyurea therapy: A report of 5 cases. Arch Dermatol. 96;132(11):1395-7.
Camos M, Cervantes F, Montoto S, et al. Acute lymphoid leukemia following polycythemia vera. Leuk Lymphoma. 99;32(34):395-398.
Chim CS, Ma SK. Der(8)t(1;8) in myeloblastic transformation of ET with hydroxyurea as the sole prior treatment. Hematol Oncol. 2005;23(2):57-60. [pmid: 16216034].
Chim CS, Ma SK. Eosinophilic leukemic transformation in polycythemia rubra vera (PRV). Leuk Lymphoma. 2005;46(3):447-50. [pmid: 15621837].
Chowdhury MM, Patel GK, Inaloz HS, et al. Hydroxyurea-induced skin disease mimicking the baboon syndrome. Clin Exp Dermatol. 99;24(4):336-7.
Cohen AD, Hallel-Halevy D, Hatskelzon L, et al. Longitudinal melanonychia associated with hydroxyurea therapy in a patient with essential thrombocytosis. J Eur Acad Dermatol Venereol. 99;13(2):137-9.
Cox C, Nowicky D, Young R. Hydroxyurea-related ankle ulcers in patients with myeloproliferative disorders: a case report and review of the literature. Ann Plast Surg. 97;39(5):546-9.
Dacey MJ, Callen JP. Hydroxyurea-induced dermatomyositis-like eruption. J Am Acad Dermatol. 2003;48(3):439-441. [pmid: 12637927].
Daoud MS, Gibson LE, Pittelkow MR. Hydroxyurea dermopathy: a unique lichenoid eruption complicating long-term therapy with hydroxyurea. J Am Acad Dermatol. 97;36(2 Pt 1):178-82.
De Benedittis M, Petruzzi M, Giardina C, et al. Oral squamous cell carcinoma during long-term treatment with hydroxyurea. Clin Exp Dermatol. 2004;29(6):605-607. [pmid: 15550132].
De Simone C, Guerriero C, Guidi B, et al. Multiple squamous cell carcinomas of the skin during long-term treatment with hydroxyurea. Eur J Dermatol. 98;8(2):114-5.
Delmas-Marsalet B, Beaulieu P, Teillet-Thiebaud F, et al. Longitudinal melanonychia induced by hydroxyurea: Four case reports and review of the literature. NOUV REV FR HEMATOL. 95;37(3):205-210.
Demircay Z, Comert A, Adiguzel C. Leg ulcers and hydroxyurea: report of three cases with essential thrombocythemia. Int J Dermatol. 2002;41(12):872-4. [pmid: 12492973].
Disla E, D''Eamour L, Cioriou M. Hydroxyurea-associated leg ulceration. Ann Intern Med. 98;129(3):252-3.
Dissemond J, Hoeft D, Knab J, et al. Leg ulcer in a patient associated with hydroxyurea therapy. Int J Dermatol. 2006;45(2):158-60. [pmid: 16445510].
Ellies P, Anderson DF, Topuhami A, et al. Limbal stem cell deficiency arising from systemic chemotherapy. Br J Ophthalmol. 2001;85(3):373-4. [pmid: 11277104].
Elliott R, Davies M, Harmse D. Dermatomyositis-like eruption with long-term hydroxyurea. J Dermatolog Treat. 2006;17(1):59-60. [pmid: 16467027].
Elliott R, Davies M, Harmse D. Dermatomyositis-like eruption with long-term hydroxyurea [2]. J Dermatol Treat. 2006;17(1):59-60.
Ellis AK, Lee DH. Tumor lysis syndrome induced by hydroxyurea therapy for leukemic transformation of polycythemia vera. Am J Hematol. 2002;71(3):237-8. [pmid: 12410589].
Famoso G, Ponzoni M, Freschi M, et al. Megakaryoblastic differentiation of myeloid sarcoma in a patient with essential thrombocythemia +AFs-4+AF0-. Leuk Lymphoma. 2006;47(11):2414-2417. [pmid: 17107920].
Ferrari D, Ticozzelli G, De Vizzi M, et al. Essential thrombocythemia and acute leukemia. Haematologica. 93;78(6):401-2.
Flamm MJ, Murty VV, Rao PH, et al. Coexistence of independent myelodysplastic and Philadelphia chromosome positive clones in a patient treated with hydroxyurea. Leuk Res. 2002;26(4):417-20. [pmid: 11839390].
Folan D W. Severe reaction to hydroxyurea. Cutis*Drug Hypersensitivity/Humans/Hydroxyurea: *adverse effects: therapeutic use/Male/Middle Aged/Psoriasis: drug therapy/Thrombocytopenia: *chemically induced
Friedrich S, Raff K, Landthaler M, et al. Cutaneous ulcerations on hands and heels secondary to long-term hydroxyurea treatment. Eur J Dermatol. 2004;14(5):343-6. [pmid: 15358575].
Furgerson JL, Vukelja SJ, Baker WJ, et al. Acute myeloid leukemia evolving from essential thrombocythemia in two patients treated with hydroxyurea. Am J Hematol. 96;51(2):137-40.
Garozzo G, Disca S, Fidone C, et al. Azoospermia in a patient with sickle cell disease treated with hydroxyurea. Haematologica. 2000;85(11):1216-8. [pmid: 11064474].
Giordano F, Savarino A, Pagni CA. Spinal meningioma during hydroxyurea therapy. A paradoxycal case report. Neurol Sci. 2002;23(3):127-9. [pmid: 12391498].
Goodrich J, Khardori N. Hydroxyurea toxicity in human immunodeficiency virus-positive patients. Clin Infect Dis. 99;29(3):692-3.
Grace RF, Shenfield GM, Grant J, et al. Recurrent pyrexia, cough and dyspnoea with hydroxyurea. Aust New Zealand J Med. 98;28(3):347.
Gropper CA, Don PC, Sadjadi MM. Nail and skin hyperpigmentation associated with hydroxyurea therapy for polycythemia vera. Int J Dermatol. 93;32(10):731-3.
Gupta AK, Rohatgi N, Rohatgi A. Hydroxyurea induced nail pigmentation. JK Science. 2003;5(1):43.
Haniffa MA, Speight EL. Painful leg ulcers and a rash in a patient with polycythaemia rubra vera. Clin Exp Dermatol. 2006;31(5):733-734. [pmid: 16901329].
Hartmann K, Nagel S, Erichsen T, et al. Cutaneous ulcers following hydroxyurea therapy. Phlebologie. 2004;33(6):202-205.
Hawkins TE, Carter JM, Romeril KR, et al. Lymphoma transformation in polycythaemia vera treated with hydroxyurea. Am J Hematol. 93;44(4):290.
Heddle R, Calvert A F. Hydroxyurea induced hepatitis. Med J AustHepatitis, Toxic: *etiology/Humans/Hydroxyurea: *adverse effects: therapeutic use/Male/Middle Aged/Psoriasis: drug therapy
Hennemann B, Bross K J, Reichle A et al. Acute alveolitis induced by hydroxyurea in a patient with myeloproliferative syndrome. Ann HematolAcute Disease/Aged/Alveolitis, Extrinsic Allergic: *chemically induced/Humans/Hydroxyurea: *adverse effects: *therapeutic use/Male/Myeloproliferative Disorders: *drug therapy/Pneumonia: chemically induced/*Pulmonary Alveoli
Henry L, Carillo S, Jourdan E, et al. Association of essential thrombocythemia and chronic lymphocytic leukemia: Absence of the V617F JAK2 mutation in the lymphoid compartment [8]. Am J Hematol. 2007;82(6):500-501.
Higuchi W, Koike T, Ihizumi T, et al. Hypereosinophilic syndrome terminating in acute myelogenous leukemia. ACTA HAEMATOL. 93;90(3):165-166.
Hirose Y, Masaki Y, Sugai S. Leukemic transformation with trisomy 8 in essential thrombocythemia: a report of four cases. Eur J Haematol. 2002;68(2):112-6. [pmid: 12061320].
Hirri H M, Green P J. Skin lesion caused by hydroxyurea. Eur J HaematolAged/Antineoplastic Agents: *adverse effects: therapeutic use/Fusion Proteins, bcr-abl/Humans/Hydroxyurea: *adverse effects: therapeutic use/Leg Dermatoses: *chemically induced: etiology/Male/Myeloproliferative Disorders: *drug therapy/Philadelphia Chromosome
Holcombe RF, Treseler PA, Rosenthal DS. Chronic myelomonocytic leukemia transformation in polycythemia vera. Leukemia. 91;5(7):606-10.
In 'T Veld BA, Slappendel AM, et al. Fever attributed to the use of hydroxyurea. NETH J MED. 97;51(3):110-113.
Jabr FI, Shamseddine A, Taher A. Hydroxyurea-induced hemolytic anemia in a patient with essential thrombocythemia. Am J Hematol. 2004;77(4):374-376. [pmid: 15558807].
Jackson GH, Wallis J, Ledingham J, et al. Hydroxyurea-induced acute alveolitis in a patient with chronic myeloid leukaemia. Cancer Chemother Pharmacol. 90;27(2):168-9.
Jacobs P, Wood L, Foster J. Hydroxyurea hypersensitivity reaction. S Afr Med J. 89;75(10):506.
Jain V, Gupta K, Nagpal N. Perimalleolar ulcers in hydroxyurea treated patients with concomitant chronic venous disease: Diagnostic pitfalls. J Coll Phys Surg Pak. 2005;15(10):658-660.
Jeevankumar B, Thappa DM. Blue lunula due to hydroxyurea. J Dermatol. 2003;30(8):628-30. [pmid: 12928534].
Karincaoglu Y, Kaya E, Esrefoglu M, et al. Development of large genital ulcer due to hydroxyurea treatment in a patient with chronic myeloid leukemia and Behcet's disease. Leuk Lymphoma. 2003;44(6):1063-1065. [pmid: 12854911].
Karsegard J, Wicky J, Mensi N, et al. Spurious glycohemoglobin values associated with hydroxyurea treatment. Diabetes Care. 1997;20(7):1211-2. [pmid: 9203471].
Kavuru MS, Gadsden T, Lichtin A, et al. Hydroxyurea-induced acute interstitial lung disease. South Med J. 94;87(7):767-9.
Kelly RI, Bull RH, Marsden A. Cutaneous manifestations of long-term hydroxyurea therapy. Australas J Dermatol. 94;35(2):61-4.
Kelsey PR. Multiple longitudinal pigmented nail bands during hydroxyurea therapy. Clin Lab Haematol. 92;14(4):337-8.
Kelsey PR, Patel K. Essential thrombocythaemia followed by multiple myeloma in the same patient. Clin Lab Haematol. 95;17(4):349-51.
Kennedy BJ, Smith LR, Goltz RW. Skin changes secondary to hydroxyurea therapy. Arch Dermatol. 75;111(2):183-7.
Kido M, Tago O, Fujiwara H, et al. Leg ulcer associated with hydroxyurea treatment in a patient with chronic myelogenous leukaemia: successful treatment with prostagladin E1 and pentoxifylline. Br J Dermatol. 98;139(6):1124-6.
Killick S, Matutes E, Swansbury J, et al. Case 17: Essential thrombocythaemia with inversion 3 terminating in acute leukaemia. Leuk Lymphoma. 98;30(56):661-664.
Kreft A, Burg J, Fischer T, et al. Essential thrombocythemia terminating in pure erythroleukemia. Am J Hematol. 2004;77(2):140-3. [pmid: 15389906].
Krsnik I, Ferro T, Garcia Suarez J, et al. Translocation t(4; 6)(q21; q27) in a case of primary thrombocythaemia in transformation. Clin Lab Haematol. 2001;23(4):259-60. [pmid: 11683789].
Kwong YL. Hydroxyurea-induced nail pigmentation. J AM ACAD DERMATOL. 96;35(2 I):275-276.
Lannemyr O, Kutti J. Hydroxyurea as a cause of drug fever in essential thrombocythaemia. Eur J HaematolAged/Aged, 80 and over/Antisickling Agents: *adverse effects: therapeutic use/Female/Fever: *chemically induced/Humans/Hydroxyurea: *adverse effects: therapeutic use/Thrombocytosis: *drug therapy
Lannemyr O, Kutti J. Hydroxyurea as a cause of drug fever in essential thrombocythaemia [4]. Eur J Haematol. 99;62(5):354-355.
Las Heras G, Junca Piera J. Nail changes after chemotherapy. Haematologica. 98;83(8):748.
Layton A M, Cotterill J A, Tomlinson I W. Hydroxyurea-induced lupus erythematosus. Br J DermatolFemale/Humans/Hydroxyurea: *adverse effects/Lupus Erythematosus, Systemic: *chemically induced/Middle Aged/Psoriasis: *drug therapy
Lazarevic VLj, Tomin D, Jankovic GM, et al. A novel t(2;17) in transformation of essential thrombocythemia to acute myelocytic leukemia. Cancer Genet Cytogenet. 2004;148(1):77-9. [pmid: 14697645].
Leo E, Kramer A, Hochhaus A, et al. Gangrene of the toes in a patient with chronic myelogenous leukemia after long-term hydroxyurea therapy. Ann Hematol. 2002;81(8):467-9. [pmid: 12224005].
Liozon E, Brigaudeau C, Trimoreau F, et al. Is treatment with hydroxyurea leukemogenic in patients with essential thrombocythemia? An analysis of three new cases of leukaemic transformation and review of the literature. Hematol Cell Ther. 97;39(1):11-8.
Liu TC, Suti R. Multiple factors in the transformation of essential thrombocythemia to acute leukemia or myelodysplastic syndrome [9]. Blood. 98;92(4):1465-1466.
Lossos IS, Matzner Y. Hydroxyurea-induced fever: Case report and review of the literature. ANN PHARMACOTHER. 95;29(2):132-133.
Majumdar G, Heard SE, Slater NGP. Reversible hyperpigmentation associated with high dose hydroxyurea. BR MED J. 90;300(6737):1468.
Marie I, Joly P, Levesque H, et al. Pseudo-dermatomyositis as a complication of hydroxyurea therapy. Clin Exp Rheumatol. 2000;18(4):536-7. [pmid: 10949738].
McLintock C, Ockelford PA. Hydroxyurea induced skin ulceration in myeloproliferative disorders. Aust N Z J Med. 2000;30(3):373-6. [pmid: 10914756].
Murphy J, Morley SM. Hydroxyurea-induced leg ulcers. Hosp Med. 2000;61(7):510. [pmid: 11091811].
Najean Y. Unwanted side effect of hydroxyurea. Ann Hematol. 96;72(2):101.
Nakahata J, Takahashi M, Fuse I, et al. Paroxysmal nocturnal hemoglobinuria with myelofibrosis: progression to acute myeloblastic leukemia. Leuk Lymphoma. 93;12(12):137-42.
Nath S, Westerman D, Campbell L, et al. Clonal “devolution” in a case of essential thrombocythemia with transformation from refractory cytopenia with multilineage dysplasia to acute myeloid leukemia. Leuk Lymphoma. 2006;47(6):1160-1162. [pmid: 16840213].
Vahidassr Ng JM. Yet another cause for drug-induced pulmonary fibrosis. J Postgrad Med. 2005;51(1):76-7. [pmid: 15793351].
Nguyen TV, Margolis DJ. Hydroxyurea and lower leg ulcers. Cutis. 93;52(4):217-9.
Obata A, Izumi T, Saitoh Y, et al. Hypereosinophilic syndrome associated with obliterative left ventricular chamber and systemic obliterative arteriosclerosis. Jpn Heart J. 91;32(5):723-30.
Oh ST, Lee DW, Lee JY, et al. Hydroxyurea-induced melanonychia concomitant with a dermatomyositis-like eruption. J Am Acad Dermatol. 2003;49(2):339-41. [pmid: 12894095].
Oskay T, Kutluay L, Ozyilkan O. Dermatomyositis-like eruption after long-term hydroxyurea therapy for polycythemia vera. Eur J Dermatol. 2002;12(6):586-8. [pmid: 12459535].
Otrock ZK, Taher AT, Mahfouz RAR, et al. Acute tumor lysis syndrome secondary to hydroxycarbamide in chronic myelomonocytic leukemia [5]. Am J Hematol. 2006;81(3):220-221.
Paleri V, Lindsey L. Oral ulcers caused by hydroxyurea. J Laryngol Otol. 2000;114(12):976-977. [pmid: 11177373].
Pamuk GE, Turgut B, Vural O, et al. Metastatic squamous cell carcinoma of the skin in chronic myeloid leukaemia: complication of hydroxyurea therapy. Clin Lab Haematol. 2003;25(5):329-31. [pmid: 12974726].
Papi M, Didona B, DePita O, et al. Multiple skin tumors on light-exposed areas during long-term treatment with hydroxyurea. J Am Acad Dermatol. 93;28(3):485-6.
Prabhash K, Bapsy PP. Hydroxyurea induced non-healing leg ulcer. Indian J Dermatol Venereol Leprol. 2005;71(1):50-2. [pmid: 16394367].
Pulik M, Lionnet F, Genet P, et al. Acute myeloid leukemia evolving from polycythemia vera in a patient treated with hydroxyurea. Am J Hematol. 96;53(3):207-8.
Puri P, Woodcock BE, O''Donnell N. Localised chronic eyedlid disease resulting from long term hydroxyurea therapy. Br J Ophthalmol. 2001;85(3):372-3.
Quintas-Cardama A, Perez-Encinas M, Gonzalez S, et al. Hydroxyurea-induced acute interstitial pneumonitis in a patient with essential thrombocythemia. Ann Hematol. 99;78(4):187-8.
Radaelli F, Calori R, Faccini P, et al. Early cutaneous lesions secondary to hydroxyurea therapy. Am J Hematol. 98;58(1):82-3.
Radaelli F, Calori R, Ripamonti C, et al. Treatment of myeloproliferative syndrome with hydroxyurea +AFs-1+AF0-. ANN HEMATOL. 96;73(4):205.
Ravandi-Kashani F, Cortes J, Cohen P, et al. Cutaneous ulcers associated with hydroxyurea therapy in myeloproliferative disorders. Leuk Lymphoma. 99;35(12):109-18.
Renfro L, Kamino H, Raphael B, et al. Ulcerative lichen planus-like dermatitis associated with hydroxyurea. J Am Acad Dermatol. 91;24(1):143-5.
Richard M, Truchetet F, Friedel J, et al. Skin lesions simulating chronic dermatomyositis during lont-term hydroxyurea therapy. J AM ACAD DERMATOL. 89;21(4 I):797-799.
Rocamora V, Puig L, Alomar A. Dermatomyositis-like eruption following hydroxyurea therapy. J Eur Acad Dermatol Venereol. 2000;14(3):227-8. [pmid: 11032076].
Ruiz-Arguelles GJ, Ruiz-Delgado GJ, Ruiz-Reyes G, et al. Anagrelide-induced relapse of a hydroxyurea-induced leg ulcer in a patient with primary thrombocythemia. Mayo Clin Proc. 98;73(11):1125.
Ruzzon E, Randi ML, Tezza F, et al. Leg ulcers in elderly on hydroxyurea: A single center experience in ph-myeloproliferative disorders and review of literature. Aging Clin Exp Res. 2006;18(3):187-190. [pmid: 16804363].
Sadamoto Y, Ueda T, Matsumoto M, et al. A case of drug-induced colitis complicating the administration of hydroxycarbamide. Endoscopy. 2002;34(6):511. [pmid: 12048644].
Salmon-Ehr V, Grosieux C, Potron G, et al. Multiple actinic keratosis and skin tumors secondary to hydroxyurea treatment. Dermatology. 98;196(2):274.
Sanchez-Palacios C, Guitart J. Hydroxyurea-associated squamous dysplasia. J Am Acad Dermatol. 2004;51(2):293-300. [pmid: 15280852].
Sandhu HS, Barnes PJ, Hernandez P. Hydroxyurea-induced hypersensitivity pneumonitis: A case report and literature review. Can Respir J. 2000;7(6):491-495. [pmid: 11121094].
Saravu K, Velappan P, Lakshmi N, et al. Hydroxyurea induced perimalleolar ulcers. J Korean Med Sci. 2006;21(1):177-9. [pmid: 16479088].
Sastre JL, Bravo A, Tembras S, et al. Leg ulcers associated with hydroxyurea therapy. Haematologica. 2003;88(2):EIM01. [pmid: 12604429].
Saviola A, Fiorani C, Ferrara L, et al. Transition of polycythemia vera to chronic myeloid leukaemia. Eur J Haematol. 2005;75(3):264-6. [pmid: 16104886].
Sawhney MPS, Mishra DK. Sarcoidosis following chemotherapy of essential thrombocythemia with hydroxyurea. Med J Armed Forces India. 2005;61(4):379-380.
Seki JT, Al-Omar HM, Amato D, et al. Acute tumor lysis syndrome secondary to hydroxyurea in acute myeloid leukemia. Ann Pharmacother. 2003;37(5):675-8. [pmid: 12708945].
Shammas F, Meyer P, Heikkila R, et al. Thrombotic microangiopathy in a patient with chronic myelogenous leukemia on hydroxyurea. Acta Haematol. 97;97(3):184-6.
Silver FS, Espinoza LR, Hartmann RC. Acral erythema and hydroxyurea. Ann Intern Med. 83;98(5 Pt 1):675.
Slobodin G, Lurie M, Munichor M, et al. Gottron's papules-like eruption developing under hydroxyurea therapy. Rheumatol Int. 2006;26(8):768-70. [pmid: 16583187].
Soppi E, Lahtinen R. Salmonella-induced reactive arthritis in a chronic myeloid leukemia patient on hydroxyurea and interferon-alpha. Clin Exp Rheumatol. 88;6(4):425-6.
Stagno F, Guglielmo P, Consoli U, et al. Successful healing of hydroxyurea-related leg ulcers with topical granulocyte-macrophage colony-stimulating factor. Blood. 99;94(4):1479-80.
Stahl RL, Silber R. Vasculitic leg ulcers in chronic myelogenous leukemia. Am J Med. 85;78(5):869-72.
Starmans-Kool MJF, Fickers MMF, Pannebakker MAG. An unwanted side effect of hydroxyurea in a patient with idiopathic myelofibrosis. ANN HEMATOL. 95;70(5):279-280.
Stasi R, Cantonetti M, Abruzzese E, et al. Multiple skin tumors in long-term treatment with hydroxyurea. Eur J Haematol. 92;48(2):121-2.
Suehiro M, Kishimoto S, Wakabayashi T, et al. Hydroxyurea dermopathy with a dermatomyositis-like eruption and a large leg ulcer. Br J Dermatol. 98;139(4):748-9.
Tajima Y, Miyazaki Y, Higashi T, et al. Primary CD30/Ki-1 positive anaplastic large cell lymphoma of the central nervous system occurring in a patient with a seventeen-year history of essential thrombocythemia. Leuk Lymphoma. 2003;44(7):1243-1245. [pmid: 12916880].
Tarumoto T, Imagawa S, Hotta T, et al. A case of bilateral heel ulcers associated with hydroxyurea therapy for chronic myelogenous leukemia. Jpn J Clin Oncol. 2000;30(3):159-162. [pmid: 10798544].
Thomas L, Ferrier E, Moulin G. Dermatomyositis-like eruption complicating hydroxyurea therapy of chronic myelogenous leukemia: report of a case and literature review.
Tothova E, Fricova M, Stecova N, et al. Leukemic transformation of polycythemia vera after treatment with hydroxyurea with abnormalities of chromosome 17. Neoplasma. 2001;48(5):389-92. [pmid: 11845984].
Tripathi A K, Ahmad R, Sawlani K K. Reversible leg ulcer due to hydroxyurea in a case of chronic myeloid leukemia. J Assoc Physicians India 2003;511014–5
Tsurumi H, Goto H, Hara T, et al. Hydroxyurea-induced fever in a patient with chronic myelogenous leukemia. Int J Hematol. 2000;72(3):386-7. [pmid: 11186000].
Vaiopoulos G, Terpos E, Viniou N, et al. Behcet's disease in a patient with chronic myelogenous leukemia under hydroxyurea treatment: a case report and review of the literature. Am J Hematol. 2001;66(1):57-8. [pmid: 11426495].
Van den Anker-Lugtenburg PJ, Sizoo W. Letter to the editor: Myelodysplastic syndrome and secondary acute leukemia after treatment of essential thrombocythemia with hydroxyurea. AM J HEMATOL. 90;33(2):152.
Van Der Klooster JM, Sucec PM, et al. Fever caused by hydroxyurea: A report of three cases and review of the literature. NETH J MED. 97;51(3):114-118.
Vargas-Diez E, Abajo P, Fraga J, et al. Chemotherapy-induced acral erythema [12]. Acta Derm-Venereol. 99;79(2):173-175.
Varma S, Lanigan SW. Dermatomyositis-like eruption and leg ulceration caused by hydroxyurea in a patient with psoriasis. Clin Exp Dermatol. 99;24(3):164-6.
Velez A, Garcia-Aranda JM, Moreno JC. Hydroxyurea-induced leg ulcers: is macroerythrocytosis a pathogenic factor?. J Eur Acad Dermatol Venereol. 99;12(3):243-4.
Velez A, Lopez-Rubio F, Moreno JC. Chronic hydroxyurea-induced dermatomyositis-like eruption with severe dermal elastosis. Clin Exp Dermatol. 98;23(2):94-5.
Venigalla P, Motwani B, Nallari A, et al. A patient on hydroxyurea for sickle cell disease who developed an opportunistic infection [1]. Blood. 2002;100(1):363. [pmid: 12096715].
Vichinsky EP, Lubin BH. A cautionary note regarding hydroxyurea in sickle cell disease. Blood. 94;83(4):1124-8.
Vomvouras S, Pakula AS, Shaw JM. Multiple pigmented nail bands during hydroxyurea therapy: an uncommon finding. J Am Acad Dermatol. 91;24(6 Pt 1):1016-7.
Vosburgh E. Pruritus secondary to hydroxyurea therapy in a woman with polycythemia vera. Am J Hematol. 92;41(1):70.
Wahlin A, Golovleva I. Emergence of Philadelphia positive chronic myeloid leukaemia during treatment with hydroxyurea for Philadelphia negative essential thrombocythaemia. Eur J Haematol. 2003;70(4):240-1. [pmid: 12656748].
Weinlich G, Schuler G, Greil R, et al. Leg ulcers associated with long-term hydroxyurea therapy. J Am Acad Dermatol. 98;39(2 Pt 2):372-4.
Westerman DA, Schwarer A, Grigg AP. Hydroxyurea-induced fever and hepatitis. Aust N Z J Med. 98;28(5):657-9.
Wirth K, Schoepf E, Mertelsmann R, et al. Leg ulceration with associated thrombocytosis: healing of ulceration associated with treatment of the raised platelet count. Br J Dermatol. 98;138(3):533-5.
Wong CC, Brown D, Howling SJ, et al. Hydroxyurea-induced pneumonitis in a patient with chronic idiopathic myelofibrosis after prolonged drug exposure. Eur J Haematol. 2003;71(5):388-90. [pmid: 14667203].
Woronzoff-Dashkoff KK, Litz CE. Acute lymphoblastic leukemia in a case of essential thrombocythemia. Am J Clin Pathol. 96;106(2):206-8.
Yasuda N, Ohmori S, Usui T. Hydroxyurea-induced gangrene of the toes in a patient with chronic myelogenous leukemia. Am J Hematol. 2000;63(2):103-4. [pmid: 10629580].
Yeh H, Lichtman SM. Hydroxyurea-induced cutaneous ulceration in older patients. J Am Geriatr Soc. 2000;48(2):232. [pmid: 10682958].
Yokota K, Tasaka T, Iwata K, et al. Huge post-operative ulcer following hydroxyurea therapy in a patient with polycythemia vera. Haematologica. 2003;88(12):ECR36. [pmid: 14688009].
Yoshida K, Saito M, Amagai M, et al. Gottron-like papules induced by hydroxyurea. Clin Exp Dermatol. 2005;30(2):191-2. [pmid: 15725256].
Young HS, Khan AS, Kendra JR, et al. The cutaneous side-effects of hydroxyurea. Clin Lab Haematol. 2000;22(4):229-32. [pmid: 11012636].
Young HS, Kirby B, Stewart EJ. Aggressive, extensive, vasculitic leg ulceration associated with hydroxyurea therapy and a fatal outcome. Clin Exp Dermatol. 2001;26(8):664-7. [pmid: 11722451].
Zaccaria E, Cozzani E, Parodi A. Secondary cutaneous effects of hydroxyurea: possible pathogenetic mechanisms. J Dermatolog Treat. 2006;17(3):176-8. [pmid: 16854761].