# Acknowledgments

The EPC thanks Allison Jonas for their assistance with literature searching, database management, and project organization, and Brenda Zacharko for her assistance with budget matters and final preparations of the report.