# Results

## Literature Search /Abstract/Article Review

The literature search process identified 12,550 citations that were deemed potentially relevant to the Key Questions. An additional 5 articles were found by hand searching, as described in Chapter 2; thus, the total number of citations retrieved was 12,555 (see Figure 3). We excluded 3,191 duplicate citations. Most duplicates came from concurrently searching MEDLINE® and EMBASE. The search strategy used in EMBASE was modeled on that which we used in MEDLINE, with similar search terms (see Appendix A *). Also, the EMBASE search engine allows the user to search the MEDLINE database as well as EMBASE, a strategy that often yields many duplicates between the two search sites. This EPC employs this strategy in order to improve the sensitivity of the search.

* Appendixes cited in this report are provided electronically at: http://www.ahrq.gov/clinic/tp/hydscdtp.htm

Figure 3. Summary of literature search and review process

In the title review process, we excluded 6,647 citations that clearly did not apply to the Key Questions. In the abstract review process, we excluded 1,451 citations that did not meet one or more of the eligibility criteria (see Chapter 2 for details). At article review, we then excluded an additional 708 articles that did not meet one or more of the eligibility criteria. An additional 223 were excluded during article review when we discovered that necessary information was not provided in the text. This exclusion process left us with 335 articles that were eligible for inclusion in the review of one or more of the Key Questions.

## Description of the Types of Studies Retrieved

Forty-seven studies, described in 53 articles, applied to Key Questions 1 or 2. There were 2 randomized controlled trials, described in 8 publications, and 37 observational studies that directly addressed the efficacy and/or effectiveness of hydroxyurea in the treatment of sickle cell disease. Eight articles described data on biomarkers as intermediate indicators of efficacy in hydroxyurea-treated patients with sickle cell disease. Sixty-four articles, many of which also included efficacy data, applied to Key Question 3: 2 RCTs of hydroxyurea in sickle cell disease described in 5 publications, 20 observational studies of hydroxyurea in sickle cell disease, 20 randomized controlled trials of hydroxyurea in other diseases, and 19 observational studies of hydroxyurea in other diseases. We reviewed 194 publications that described case reports about the toxicity of hydroxyurea. We identified 49 studies that applied to Key Question 4 concerning barriers to the care of patients with sickle cell disease.

## Key Question 1: What is the Efficacy (results from clinical studies)of Hydroxyurea Treatment for Patients who have Sickle Cell Disease?

## Key Question 2: What is the Effectiveness (in everyday practice) of Hydroxyurea Treatment for Patients who have Sickle Cell Disease?

### Description of Randomized Trials

We identified eight published reports describing results from two randomized controlled trials of hydroxyurea for the treatment of sickle cell disease (Appendix C, Evidence Table 1). These reports presented the results from the MSH, ^21,^ ^22,^ ^39^–^42^ an extended followup of the participants in the MSH, ^43^ and a pediatric study in Belgium. ^44^ The MSH began enrollment at multiple centers in North America in 1992, and the results were published in 1995. This study enrolled 299 adults. The Belgian study began enrollment in 1992 at two centers in Europe, and the results of this study were published in 1996 after enrollment of 25 patients. The Belgian study had a crossover design; patients were randomized to receive hydroxyurea or placebo for the first 6 months and then to receive the other treatment for the next 6 months. Hematological outcomes were reported as the change from baseline after 6 months of hydroxyurea, and clinical outcomes were compared between the placebo and hydroxyurea arms. The methods used for dose escalation and monitoring for toxicity were similar in the two studies, except the maximum dose was 35 mg/kg/day in the MSH and 25 mg/kg/day in the Belgian study.

Description of the quality of the studies. Both trials had rigorous eligibility criteria designed to select patients with severe sickle cell anemia or sickle α -thalassemia and minimize the risk of known toxicities. The methodological quality of the MSH was excellent (Jadad score of 5, out of a maximum of 5) and that of the Belgium study was moderate (Jadad score of 3), because the method of masking was not described (Appendix C, Evidence Table 2). Both the MSH and the Belgian study provided a placebo control with masking of patients, but only the MSH study masked the providers and the endpoint adjudication panel. In the MSH, 53 patients (18 percent) had permanent or extended cessation of the study medication: 21 percent in the hydroxyurea group and 14 percent in the placebo group. Frequent reasons for discontinuation were pregnancy (n=16), inactivity (n=18), myelotoxicity at 2.5 mg/kg/day or “simulated toxicity” (n=5), and a need for long-term transfusion therapy (n=5). ^39^ The Belgian investigators excluded three patients (14 percent) after 4 to 5 months for failing to make the required monthly visits.^44^

Description of the included patients. A description of the patients is given in Appendix C, Evidence Table 3. The MSH included only adults (mean age, 30.5 years), and approximately half of the participants were male. The Belgian study included mostly children (median age, 9 years; range, 2 – 22 years), and approximately half were male. The majority of patients in both studies were African or African American and had sickle cell anemia. The β-globin haplotype was reported only in the MSH study; about 40 percent were homozygous for the Benin haplotype, 20 percent were heterozygotes with the Benin/Central African Republic (CAR) haplotype, and the remainder had other combinations.

### Description of Observational Studies (Pre/Post Design or Non-Randomized Control Group)

Design. Our analyses included the results of 37 observational studies of hydroxyurea use in patients with sickle cell disease: 19 in North America, 11 in Europe, 2 in the Middle East, and 3 in Central or South America (Appendix C *, Evidence Table 4). The earliest studies we identified were published in 1992, ^45,^ ^46^ and one-quarter of the studies were published in the past 2 years. The studies ranged in size from only 8 patients in a cytotoxicity study ^47^ to 225 patients in the large French cohort. ^48^ More studies were designed to enroll children only (n=20) than adults only (n=12).

The majority of the studies are best described as pre/post studies in which the patients' clinical parameters were described prior to starting hydroxyurea and again after they had been on the drug for a period of time. Nine of the studies were retrospective, ^45,^ ^48^–^55^ two were cross-sectional, ^56,^ ^57^ and the rest were prospective studies. Three studies described comparison groups of patients who were not treated^58,^ ^59^ with hydroxyurea. ^60^–^62^

The study goals varied markedly (described in Evidence Table 4). The majority aimed to assess the long-term safety and efficacy of hydroxyurea. Some studies, however, were more specialized, including two that assessed the effect of the drug on transcranial Doppler (TCD) velocities, ^62,^ ^63^ one that assessed the efficacy of a low dose of hydroxyurea, ^50^ three that specifically assessed splenic function, ^56,^ ^64,^ ^65^ one that focused on cutaneous adverse effects, ^66^ one that assessed albuminuria, ^49^ one that assessed secondary stroke, ^67^ and several that looked at malignancy and cytotoxic effects of the drug. ^47^ Most studies reported both efficacy and toxicity data; however, 8 were primarily toxicity studies, ^47,^ ^48,^ ^53,^ ^57,^ ^66^ ^55,^ ^64,^ ^68^18 were primarily efficacy studies, ^45,^ ^62,^ ^63,^ ^69^ ^46,^ ^50,^ ^59^–^61,^ ^70^–^78^ and 11 were primarily effectiveness studies, ^49,^ ^51,^ ^52,^ ^56,^ ^58,^ ^65,^ ^67,^ ^79^–^82^ although the designs of the efficacy and effectiveness studies were often similar. Toxicity studies without efficacy data are not included in Evidence Table 8. ^53,^ ^57^

Patient Clusters. We identified four clusters of studies based on the patient populations examined; this approach was taken because of our concern that some patients might have been described in more than one publication. One cluster was comprised of manuscripts related to the Safety of Hydroxyurea in Children with Sickle Cell Anemia (HUG-KIDS) study. HUG-KIDS was a high-quality phase I/II study that began recruiting children in December, 1994 and continued through March, 1996. The first of these studies that we included in this cluster was primarily a toxicity study. ^68^ The second included efficacy data from the children who reached the MTD during the study. ^73^ The third study was a pre-post effectiveness study that included 15 of the children who had been enrolled in HUG-KIDS. ^81^

The second cluster was the Hydroxyurea Safety and Organ Toxicity (HUSOFT) cluster, which consisted of two studies. ^60,^ ^72^ The first was the HUSOFT study itself, which was a cohort study of hydroxyurea use in young children with Hb SS. ^60^ In this publication, the CSSCD cohort was described as a comparison group. The second study was an extension of HUSOFT study, in which investigators followed the patients for a longer time. ^72^

In our third cluster, we grouped studies from a group of investigators in France. The patients were recruited from centers participating in the French Study Group on Sickle Cell Disease. The first study was a pre-post efficacy study; ^76^ the second study was also an efficacy study that included some (or all) of the patients who had been described in the first study. ^75^ The third publication was a survey of French physicians treating children with hydroxyurea to assess toxicity. ^55^ We expect that those children who were enrolled in the first study were also described by their physicians in the survey. ^76^ Finally, the most recent study was a cohort study^48^ to explore toxicity, which involved recruiting patients who had been in the earlier studies and those identified by the survey. ^55^

The fourth cluster consisted of two publications from the Belgian Sickle Cell Group. ^58,^ ^82^ Both publications described the experiences of patients in their registry, with the latter study including more patients. ^82^ To our knowledge, the studies outside these four clusters included no overlapping patients.

Interventions. The initial dosage and titration schedule for hydroxyurea varied little across studies, with most starting at 15 or 20 mg/kg and titrating upward by 5 mg/kg at some interval (ranging from every 4 weeks to every 6 months) or according to clinical response. One study specifically tested the efficacy of the drug without up-titration, ^50^ and the HUSOFT study did not involve titration. ^60^ A number of the observational studies did not include any description of the dosages received by the patients.

Description of the quality of the studies. The studies that were evaluated with our 16-point scale for assessing the quality of observational studies received between 27 percent ^47^ and 93 percent^77^ of the possible points (Appendix C, Evidence Table 5). There were eight high-quality studies that received more than 80 percent of the quality points. ^46,^ ^64,^ ^68,^ ^70,^ ^73,^ ^76,^ ^77,^ ^81^ There was a small but significant decline in quality score over the years (p=0.01). Most of the studies appropriately chose objective outcomes to report, and most described their interventions with adequate detail. Studies were less complete in their description of their source population, i.e., the population from which their participants were drawn; they were also less complete in their description of the inclusion criteria for their study and in their description of the characteristics of the included patients. Authors did a particularly poor job of describing how complete the adherence to the intervention was and of describing losses to followup. For cohort studies, inadequate description of losses to followup can be an important source of bias. There were no high-quality studies that directly addressed the effectiveness of treatment with hydroxyurea for sickle cell disease, an important issue for the implementation of a therapy. The two studies that used a survey design were not considered high-quality because they provided little detail about the surveyed patients and providers and did not use any validated instruments for collecting information; however, they were probably adequate for their purpose, which was to collect toxicity data from providers. ^53,^ ^55^

Description of the included patients. A description of the included patients is given in Appendix C, Evidence Table 6. Although not all studies reported the sex of the enrolled patients, for those that did, the percentage of males ranged from 40 percent^77^ to 74 percent. ^76^ The majority of the studies included patients with Hb Sβ thalassemia and with Hb SC disease in addition to Hb SS.

HUSOFT was a study of very young children (mean age of 1.3 years, with a range from 0.5 to 2.3 years). ^60^ The 20 pediatric studies had mean or median ages ranging from 1.3 to 14 years, and the 12 adult studies had mean or median ages from approximately 21 to 33 years. Two studies included adults and children, ^58,^ ^70^ and two did not describe the age range. ^69,^ ^79^ Three of the studies from Europe were exclusively of Caucasian patients. ^71,^ ^74,^ ^78^ Few studies described the clinical activity of their cohorts upon entry, although this information could often be inferred from the inclusion and exclusion criteria. The duration of observation of the enrolled patients varied markedly both across studies and within studies. The studies with the longest median followup times were in the range of 36 to 45 months. Some individuals within each study were followed for much longer, although they were not necessarily treated with hydroxyurea for the duration of their followup.

### Efficacy and Effectiveness of Hydroxyurea in Children

The Belgian RCT, a small placebo-controlled study, reported hematological outcomes as the change from baseline after 6 months of treatment with hydroxyurea (Appendix C, Evidence Table 7). In the hydroxyurea group hemoglobin increased by a mean of 0.4 g/dl, and the absolute mean increase in Hb F was 10.7 percent (p<0.001). ^44^ For these children, the rate of hospitalization and number of days hospitalized per year were significantly lower for the hydroxyurea group (1.1 admissions, p=0.0016 and 7.1 days, p=0.0027) than for the placebo group (2.8 admissions and 23.4 days).

Among the observational studies, more reported hematological outcomes than reported clinical outcomes. Hb F% was reported as an outcome in 17 studies (Table 1; Appendix C, Evidence Table 8). In all the studies that reported Hb F% before and during treatment with hydroxyurea, the HbF% increased substantially while patients were being treated. The mean pre-treatment Hb F% ranged from 5 to 10 percent, and the post-treatment values were in the range of 15 to 20 percent. The percentage of F cells was less frequently reported, but it increased from baseline in three of the four pediatric studies in which it was reported. ^68,^ ^72,^ ^75^ In the fourth study, the maintenance of a stable percentage of F cells and Hb F% over 104 weeks of treatment, rather than the decline usually seen in young children, was attributed to hydroxyurea therapy. ^60^ Three of these observational studies were retrospective. ^49^–^51^ Of these, two reported increases in Hb F% that were comparable to those in the prospective studies. ^49,^ ^50^ One brief report described 226 patients who had taken hydroxyurea and compared the 38 patients who died to the remainder who survived. ^51^ The Hb F% increase was greater in the patients who died than among those who survived, but these two groups were substantially different before treatment. The authors concluded that not all patients benefit from hydroxyurea. Hemoglobin concentration increased modestly (roughly 1 gm/dl) but significantly across these studies.

Table 1 Efficacy of Hydroxyurea in Observational Studies of Children with Sickle Cell Disease

Outcome | Number of Studies Reporting | Magnitude and Consistency of Effect
Hb F% | 17 | 93% to 366% increase*
Hemoglobin | 16 | 5% to 20% increase
Pain Crises | 4 | No difference in 1; no baseline data in 1; and significant reductions in 2
Hospital Admissions | 4 | 56% to 87% decline in yearly rate
Transfusions | 1 | Decreased for 3.9/ year to 0.43/ year
Mortality | 4 | Very rare events
Neurological Events | 3 | Comparable stroke rates as on chronic transfusion, stable brain images

The frequency of pain crises was reported as an outcome in five pediatric studies. ^50,^ ^59,^ ^64,^ ^72,^ ^82^ In the retrospective study by Svarch et al., the frequency of pain crises declined from a median of 3 per year to a median of 0.8 per year while patients were on treatment, with a median followup time of 24 months. ^50^ It is particularly important to note that these results were obtained in a resource-poor environment (Central America) and used a fixed dose of hydroxyurea of 15 mg/kg/day. Another study reporting pain outcomes was a small study by Hankins et al. ^72^ that prospectively followed 17 children who had been enrolled in HUSOFT during a 4-year extension study. The authors reported 33.8 pain events requiring hospitalization per 100 patient-years while their patients were on treatment, a rate that did not differ from that reported for untreated patients in the CSSCD cohort (32.4 per 100 patient-years, p=0.87). The authors felt that differences in the methods of collecting pain data in their study and in the CSSCD may have biased the results toward a finding of no difference. They observed fewer episodes of acute chest syndrome than were seen in the CSSCD. A small, high-quality study found a decrease in pain events from 3.1 per year in the year prior to hydroxyurea therapy to 1.2 per year during 18 months of therapy. ^64^ Similarly, in a 12-month study by Santos et.al, pain frequency decreased from a median of four episodes per year to two per year during the year of therapy (p=0.0009). ^59^ In the most recent study from the Belgian Sickle Cell Registry, patients had 2.2 pain crises per year that required hospitalization while on treatment, although it is not clear what the baseline rate was for their population. ^82^

Hospitalization rates were reported in four studies. Again, in the retrospective Central American study, the hospitalization rates decreased to 0.5 per year while on treatment from a baseline rate of 4 per year. ^50^ In the study by Oliveri, rates declined by 75 percent, to 1.7 per year from 6.7 per year; ^64^ compliance with medication use was very high in this study. Similarly, in a small study of severely ill children, the hospitalization rates dropped to 3 per year from 7 per year. ^77^ In the Belgian Registry, hospitalization rates declined to 1.1 per patient-year from 3.2 per patient-year after 3 years. ^82^

Two studies reported TCD velocities. ^62,^ ^63^ In the study by Kratovil et al., the mean maximum velocity decreased on treatment to 111 cm/sec from a mean maximum of 125 cm/sec. ^62^ A control group that was not treated with hydroxyurea had an increase in velocity over the same time period of 4.7 cm/sec. In the recent prospective study by Zimmerman et al., 37 children had TCD measurements prior to starting hydroxyurea. ^63^ The children (n=36) reached a stable MTD of 27.0 mg/kg/day and had repeat Doppler studies after a mean of 10 months. Velocities decreased significantly in the right and left middle cerebral arteries, right and left anterior cerebral arteries, and left posterior cerebral artery. In 14 of 15 children with conditional baseline TCD velocities, the values improved; in 5 of 6 with abnormal velocities, whose families refused transfusions, the velocities decreased to less than 200 cm/sec.

One study assessed the impact of hydroxyurea on secondary stroke prevention by enrolling 35 children who needed to discontinue their chronic transfusion protocol. ^67^ The average dose of the drug was 27 mg/kg/day, and the children were treated for a mean of 42 months. Seven children had recurrent ischemic events, for a rate of 5.7 per 100 patient-years. We noted, for comparison, that this rate was higher than the 2.2 per 100 person-years reported in a retrospective cohort study of children who received ongoing transfusions, ^83^ but it was better than the 70 percent prevalence of recurrent stroke seen in the first year after discontinuing transfusion without alternative treatments. ^84^ One other study reported that brain images obtained by MRI were stable during the course of treatment in 24 of 25 children. ^65^ In the Belgian Registry, during 426 patient-years of hydroxyurea treatment, the rate of central nervous system events (stroke or transient ischemic attacks) was 1.3 per 100 patient-years, but no comparison rate was provided. ^82^

Four studies assessed splenic function during hydroxyurea therapy. ^56,^ ^59,^ ^64,^ ^65^ One found no difference in the 12 children in whom the number of pitted red blood cells was counted. ^64^ A cross-sectional study used Howell-Jolly bodies as the outcome: ^56^ In the group of patients with spleens, patients on hydroxyurea therapy had a greater number of Howell-Jolly bodies than did those in the group not taking the drug. This relationship was true as well for the patients without spleens, suggesting that Howell-Jolly bodies are not simply a measure of splenic function. In a prospective study of 52 children, of whom 43 had had spleen function measured with scintigraphy both at baseline and on therapy, 6 patients (14 percent) completely recovered splenic function, and 2 (5 percent) had preserved splenic function after a median of 2.6 years of hydroxyurea at the MTD. ^65^ In the study by Santos et al., splenic function as measured by scintigraphy improved in 10 of 21 children was stable in 8, and worsened in 3. ^59^ A retrospective study reviewed the efficacy of hydroxyurea in reducing the progression of microalbuminuria^49^: Of the 17 treated patients without microalbuminuria at baseline, 16 remained free from microalbuminuria; 4 of 9 patients with baseline microalbuminuria normalized their urinalysis during treatment. The study by Santos and coworkers was the only one to describe transfusion use in children, reporting that the transfusion rate decreased from 3.9 per year to 0.43 per year in their 21 treated patients. ^59^

### Efficacy and Effectiveness of Hydroxyurea in Adults

In the MSH RCT, significant hematological effects of hydroxyurea after 2 years (relative to the placebo arm) included a small mean increase in total hemoglobin (0.6 g/dl) and moderate increases in fetal hemoglobin (3.2 percent) and mean corpuscular volume (MCV; 10.1 fl) (Appendix C, Evidence Table 7). ^21,^ ^39,^ ^40^ The median number of painful crises was 2.5 per year for those receiving hydroxyurea, as compared to 4.5 per year (a 44 percent decrease, p<0.001), and the time to first painful crisis was 3 vs 1.5 months (p<0.01). There were fewer episodes of acute chest syndrome (25 vs 51, p<0.001), transfusions (55 vs 79 patients, p=0.002, and 423 vs 670 units, p=0.002), but no significant differences in deaths (2 vs 6), strokes/chronic transfusion (2 vs 3), or hepatic sequestration (1 vs 3). ^39^ In the long-term followup study, which was observational after the initial period of randomization, the mortality rate was 40 percent lower (p=0.04) when patients were taking hydroxyurea (1.5 per 3-month period) than when taking placebo or no treatment (2.6 deaths per 3-month period). However, the long-term mortality, when analyzed according to the initial treatment assignment in the 2-year randomized trial, was similar for the hydroxyurea (3.1 per 100 person-years) and placebo (3.6 per 100-person-years) groups. The rates of stroke, sepsis, and renal and hepatic failure were also similar between the two groups. ^43^

The MSH trial also included an evaluation of costs and quality of life. Annualized total costs were $16,810 for the hydroxyurea group and $22,270 for the placebo group (p=0.21), with significantly lower costs for hospitalization for pain in the hydroxyurea group ($12,160, p<0.05) than the placebo group ($17,290). ^22^ The hydroxyurea and placebo groups were similar in terms of all the quality of life measures, but participants with the greatest increase in Hb F (upper half of the change in Hb F) had significantly better “general health now” (p<0.001), decreased pain by 4-week recall (p=0.004), and better general health (p=0.001). ^42^ A sub-study of the MSH, completed at a single institution, evaluated exercise capacity; which increased in the hydroxyurea group when compared to the placebo group. This improvement was accompanied by an increase in weight and decrease in the resting heart rate in the hydroxyurea group (3.2 kg and -14 beats/min, as compared to the placebo group's 1.8 kg and -4 beats/min). ^41^

In the six prospective, observational studies of adults that reported hematological outcomes, Hb F% increased significantly in all six studies (Table 2; Appendix C *, Evidence Table 8). ^45,^ ^46,^ ^71,^ ^74,^ ^78,^ ^80^ The mean baseline Hb F% ranged from 4 percent to 12 percent, and during hydroxyurea treatment it ranged from 10 percent to 23 percent. The greatest increase was seen in the study by Voskaridou et al., ^78^ which was a prospective study of Caucasian patients with Hb Sβ^+^ thalassemia and Hb Sβ^0^ thalassemia who were treated with high doses of hydroxyurea, up to 2.5 g/day. These 14 patients had an increase from a mean of 3.6 percent (standard deviation [SD]=2.1) to 23 percent (SD=7.7). The smallest increase in Hb F% was seen in the study from Brazil, which reported outcomes by haplotype. This was a study of 22 patients; the greatest increase was among patients who had a homozygous Bantu haplotype (n=9 patients), from 4 percent to 9 percent (p=0.003). ^80^ As in the pediatric studies, there was a small increase in hemoglobin in most studies. The retrospective study by Loukopoulos reported hematological outcomes very comparable to those seen in the prospective studies. ^74^

Table 2 Efficacy of Hydroxyurea in Observational Studies of Adults with Sickle Cell Disease

Outcome | Number of Studies Reporting | Magnitude and Consistency of Effect
Hb F% | 6 | 68% to 536% increase
Hemoglobin | 5 | 0% to 66% increase*
Pain Crises | 3 | 68% to 84% decline in yearly rates
Hospital Admissions | 3 | 18% to 32% decline in yearly rates
Transfusions | None
Mortality | None
Neurological events | None

0 The population in the study with no increase in hemoglobin was entirely composed of patients with HbSB or SB^+^thalessemia, but these patients had a large increase in Hb F% (536%).

The number of pain crises was described in three studies. ^46,^ ^61,^ ^71^ The frequency of crises experienced by the 32 patients who completed the study by Charache et al. decreased from 4 per 6 months (range 0 to 20) to 1.3 per 6 months (range 0 to 9), although this difference was not statistically significant. In a study of Sicilians with Hb Sβ^+^ thalassemia and Hb Sβ^0^ thalassemia, the frequency of crises decreased from a mean of 7 (median of 9) per year to a mean of 1.1 (median 1.8) per year (p<0.0001). ^71^ These results included all crises, not just pain crises. In a non-randomized study comparing patients receiving hydroxyurea to those receiving cognitive behavioral therapy, those receiving the drug had fewer pain crises (1.4 per year compared to 4.3 per year, p≤0.05), although this was not a strong design on which to base such an outcome. ^61^

Hospitalization rates also decreased for adults treated with hydroxyurea. In the study of Sicilians, the number of hospitalized days in a year declined from 22.4 days to 1.2 days (SD =2.3; p<0.0001). In a retrospective effectiveness study by Ferguson et al., the rates of hospitalization declined from baseline in the group that was treated for longer than 24 months (to 2.1 per year from 3.1 per year, p=0.04). ^52^ For the group treated for fewer than 24 months, however, the investigators did not find a significant difference in hospitalization rates from baseline. In the study comparing hydroxyurea to cognitive behavioral therapy, the patients receiving the drug and those receiving behavioral therapy had similar hospitalization rates (1.1 per year [SD= 2.4] versus 0.9 per year [SD=1.2]). ^61^

Several of the studies reported additional efficacy outcomes. In the study by Loukopoulus et al., a mean clinical severity score was calculated based on an arbitrary scale that quantified pain and duration of pain. ^74^ Over 12,018 patient-weeks of treatment, the severity score declined to 81.7 from 1182. In comparing the group receiving hydroxyurea to the group receiving cognitive behavioral therapy, the investigators reported a significant improvement in General Health Perception from the SF36 Health Survey among those receiving the drug. ^61^

Ferster et al. enrolled children and young adults in their study, ^58^ while Al-Jam'a et al. enrolled adults and children older than 5 years. ^70^ Ferster et al. demonstrated hematological benefit, with an increase in Hb F% from a mean of 7.3 to 16.7 percent (p<0.01) and an increase in hemoglobin from 8.2 g/dl to 8.8 g/dl (p<0.01). ^58^ Also, none of the patients had a stroke during the study, despite the fact that this was a sick population, with 9 of the 93 having a history of prior stroke and 19 having a history of acute chest syndrome. The rate of hospitalization for those receiving hydroxyurea was 1.1 per patient-year, and the rate of acute chest syndrome was 3.5/100 patient-years. In the study of Saudi Arabian patients, Al-Jam'a et al. demonstrated good hematological outcomes, with an increase in Hb F% from 12.6 percent to 25.7 percent (p<0.05), as well as clinical benefit, with a decrease in hospitalization to a mean of 0.93 per year (p<0.0001) and a decrease in hospital days to 5.1 per year from 34 per year (p<0.05).

Predictors of benefit from hydroxyurea treatment. Many studies have explored predictors of benefit from hydroxyurea (Table 3); one was designed specifically to address this question. ^73^ Predictors of the fetal hemoglobin response to hydroxyurea were most frequently reported. In the MSH study, Hb F% increased to a greater extent in participants with a lower rate of painful events and, at baseline, reticulocytes greater than 300,000/μl, F reticulocytes greater than 12 percent, absolute neutrophil count (ANC) greater than 7500/μl, and fetal hemoglobin greater than 7.5 percent. Hb F% increased less in men, to a lesser degree in those with the CAR haplotype, with less than 80 percent adherence to therapy, or with fewer than two episodes of hematological toxicity during treatment. ^21^ In a Phase II study from the same group, Hb F was associated with the most recent plasma level of hydroxyurea, as were Hb F and white blood cell counts at baseline. ^46^ Similarly, in children, an increase in Hb F% was associated between higher F reticulocyte counts at baseline^75^ and adherence to therapy, ^52^as well as increases in hemoglobin and MCV from baseline, decreases in reticulocytes and white blood count from baseline, and lower reticulocyte and white blood counts at the MTD. ^73^ A pediatric study also identified an association with a higher baseline hemoglobin and greater response. ^73^ Neither adult nor pediatric studies found that Hb F% was predicted by age; ^40,^ ^46,^ ^73,^ ^75^; the pediatric studies did not find that gender, hematological toxicities, ^73^ or haplotype^75^ predicted response.

Table 3 Predictors of Benefit from Hydroxyurea in Studies of Sickle Cell Disease

Author, year | Predictors of Benefit from Hydroxyurea Treatment | Outcome
Trials
Steinberg, 1997^40^ | Lower baseline crisis rates, baseline reticulocyte count (>300,000/ul), women, absence of CAR haplotype, F reticulocytes > 12%, absolute neutrophil count >7500/μl, Hb>7.5%, >80% adherence, and >2 hematological toxicity episodes during treatment | Hb F%
Ferster, 1996^44^ | Not associated with the initial Hb F level, white blood cell count, or platelet count | Hb F%
Ballas, 2006^42^ | Higher Hb F%, higher baseline quality of life, lower baseline daily pain, baseline crisis rate <6/year | Quality of life
Hackney, 1997^41^ | Men compared to women | Aerobic power
Charache, 1995^21^ | Prior crisis rate, lower absolute neutrophil count, higher reticulocyte count, and MCV | Painful episodes
Observational Studies
Charache, 2992^46^ | Last plasma HU level, higher initial Hb F%, and higher white blood count | Hb F%
Hankins, 2005^72^ | Dose increase | Hb F%
Loukopoulous, 1998^69^ | Females | Hb F%
Loukopoulous, 2000^74^ | Low Hb F at baseline; great similarity in response between siblings | Hb F%
Maier-Redelsperger, 1998^75^ | Increase in MCV and higher initial F reticulocytes; not age, gender, haplotypes; Hb F% at 6 months did not predict maximum | Hb F%
Vicari, 2005^80^ | Not age, not sex | Hb F%
Ware, 2002^73^ | Positively associated with Hb F% at baseline, Hb at baseline, and MTD achieved. Negatively associated with # of pills returned. Not age, not sex, not hematologic toxicities. Other predictors: change in Hb from baseline to MTD, MCV change from baseline to MTD, decline in reticulocytes from baseline and number at MTD, white count decline from baseline and white count at MTD | Hb F%
Ferguson, 2002^52^ | Duration and completeness of therapy | Hospital admissions
Ferster, 2001^58^ | Not predicted by hematological values | Hospital admissions
Zimmerman, 2007^63^ | Higher TCD velocity at baseline predicted response | Cerebral blood flow velocity
Ware, 2004^67^ | Lower recurrence for those who initiated HU therapy before discontinuation of transfusion therapy | Recurrent stroke
Kratovil, 2006^62^ | Dose of HU | Cerebral blood flow velocity

CAR = Central African Republic; Hb F%=fetal hemoglobin percentage; MCV = mean corpuscular volume; HU = hydroxyurea; MTD = maximum tolerated dose; TCD=transcranial Doppler

Clinical responses to hydroxyurea, i.e., a decreased rate of painful episodes, were associated with the baseline rate of painful episodes, decreases in the absolute neutrophil count and absolute reticulocyte count, and increases in MCV. ^21^ Men treated with the drug had greater absolute increases in aerobic power (p<0.05) than did women. ^41^ Two pediatric studies from Belgium did not identify any predictors of clinical response; ^44,^ ^58^ however, other observational studies did do so. Hospital admissions were significantly decreased in adults with at least 2 years of hydroxyurea treatment with no interruptions exceeding 2 weeks, when compared to those with a shorter duration of therapy or interruptions. ^52^ In children, an increasing dose of hydroxyurea was associated with a decrease in cerebral blood flow velocity. ^62^ Recurrent stroke in children receiving hydroxyurea for secondary stroke prevention was associated with older age, initiation of hydroxyurea after chronic transfusion had been stopped, and a higher ANC during treatment.^67^

Response to hydroxyurea treatment according to genotype. As described above, studies were generally stratified by age (adult or pediatric); however, other subgroups were less thoroughly investigated. While the majority of patients studied were homozygous for Hb S, most of the studies had some patients with other genotypes. Five studies reported outcomes stratified by genotype (Table 4). The most detailed study was that by Loukopoulous et al., which described all of the hematological outcomes in their small patient sample, stratifying them by sex and genotype. ^74^ Only a single study reported specific outcomes for patients with Hb SC disease; this study demonstrated less improvement with hydroxyurea treatment in this subgroup, and these seven children were less able to tolerate dose increases. ^81^ In general, patients with Hb Sβ^0^ thalassemia or Hb Sβ^+^ thalassemia responded to treatment in a manner comparable to that of patients with Hb SS.

Table 4 Outcomes of Hydroxyurea Use in Sickle Cell Disease Reported by Genotype

Author, year | Comments
Santos, 2002^59^ | More marked improvement in splenic function in patients with Hb SS than in patients with HbSβ0-thalassemia. Thought to be due to less severely impaired splenic function at baseline in patients with Hb Sβ^0^-thalessemia
Loukopoulos, 2000^93^ | No increase in Hb among patients with Hb Sβ^+-^thalassemia; increase in the Hb SS and HbSβ^0^-thalessemia groups. The β-thalassemia genotype did not affect Hb F response; substantial increase in all groups.
Zimmerman, 2004^81^ | Hb F % increased from baseline in all genotypes except those with Hb SC disease. Patients with severe forms of SCD (Hb SS, HbS/β^0^, and Hb S/OArab) had significant increases in hemoglobin concentration, whereas patients with Hb SC or HbSβ^+/ -^thalassmia had minimal changes in Hb concentration. Patients with Hb SC tolerated less HU before toxicity developed.
el-Hazmi, 1992^45^ | Increase in Hb F% for patients with Hb SS and patients with HbSβ^0^-thalessemia
Maier-Redelsperger, 1998^75^ | All patients in study were homozygous SS; no difference in response to HU by β-globin gene haplotypes.

Studies of biomarkers suggesting a drug effect. We identified eight studies that compared potential surrogate markers of disease severity or response in patients treated with or without hydroxyurea. ^85^–^92^ These studies were all cross-sectional or cohort studies with at least one comparison group (Appendix C *, Evidence Tables 9–11). The studies enrolled patients from North America (5), Europe (2), or Central and Latin America (1). The description of the eligibility criteria was often quite limited, and the majority of studies were of moderate to poor quality. There was only limited information regarding patient characteristics and the starting dose, monitoring, and titration of hydroxyurea.

Four studies included a report of hemoglobin and Hb F levels among groups and reported increases in total and fetal hemoglobin that were comparable to those of the other observational studies in sickle cell disease after treatment with hydroxyurea. ^86,^ ^87,^ ^90,^ ^92^ In three studies, treatment with hydroxyurea was associated with significantly increased levels of nitric oxide metabolites, ^87,^ ^91^ cyclic guanosine monophosphate, ^87^ and nitric oxide synthase and with reduced levels of arginase. ^86^ Another study identified lower levels of endothelin-1, a potent vasoconstrictor, in children treated with hydroxyurea for more than 12 months, when compared to untreated patients. ^88^ These molecules may be biomarkers of abnormal vasoreactivity in sickle cell disease that may contribute to vaso-occlusive complications. Other potential biomarkers of vaso-occlusion were the significant decreases in rigidity and rates of elastic shear in patients with sickle cell disease who had been treated with hydroxyurea, when compared to those in untreated sickle cell disease patients. ^85^ However, these values were still significantly higher than those in controls without sickle cell disease. A small study failed to show differences in tumor necrosis factor-α in adults with Hb SS treated with and without hydroxyurea, ^89^while a study with similar design (comparing adults with Hb SS with and without vaso-occlusive complications and treated with and without hydroxyurea) described a higher percentage of oxyhemoglobin and a lower percentage of reduced hemoglobin in patients on hydroxyurea, with or without vaso-occlusive complications. ^91^ The higher percentage of oxyhemoglobin may reflect decreased adhesion and more rapid transit of the cells through the capillary beds. A final pediatric study demonstrated significant decreases in total bilirubin (most likely secondary to decreased hemolysis and release of heme) after treatment with hydroxyurea. ^90^ The baseline level and absolute decrease in bilirubin were strongly correlated with promoter polymorphisms of uridine diphosphoglucuronate glucuronosyltransferase 1A (UGT1A). The lowest levels of bilirubin, both before and during treatment, were seen in children with the UGT1A 6/6 genotype; intermediate levels were seen in the heterozygotes (6/7), and the highest levels were seen in those with the UGT1A 7/7 genotype. These diverse studies of biomarkers suggest possible mechanisms for hydroxyurea's clinical benefits in addition to its ability to increase Hb F and reduce hemoglobin polymerization.

Strength of the evidence regarding the efficacy and effectiveness of hydroxyurea. Based on one RCT in children and many observational studies, some of which were of high quality and most of which were consistent in their findings, we graded the evidence as follows: We concluded that there was a high grade of evidence to support the contention that hydroxyurea raises Hb F in children, and subsequent research is unlikely to change our estimate of that effect, except perhaps in unique populations (such as infants or patients with Hb SC). There was moderate evidence to support the claim that hydroxyurea reduces the frequency of pain crises, and a high grade of evidence to support the contention that treatment reduces the frequency and/or duration of hospitalization in children. There was only a low grade of evidence to support the claim that hydroxyurea reduces neurological events in children and insufficient evidence to allow any conclusions regarding transfusion frequency.

Based on one high-quality RCT in adults and many observational studies, we concluded that there was a high grade of evidence to support the conclusion that hydroxyurea raises Hb F in adults with sickle cell disease, and future research is unlikely to substantially alter these conclusions. There was also high-grade evidence that the drug reduces the frequency of pain crises and that it reduces the frequency and/or duration of hospitalization in adults. There was also high-grade evidence that it reduces transfusions, but only low-grade evidence, from the observational followup of patients in MSH, that it reduces mortality. The evidence base was insufficient to allow us to comment on neurological events in adults (Table 5).

Table 5 Summary of the Evidence

Outcomes | Evidence Grade | Basis for Grade
Key Question 1 and 2—Children
Increase in fetal hemoglobin | High | One good RCT, plus consistent observational studies
Reduction in pain crises | Moderate | One good RCT; inconsistent observational studies
Reduction in hospitalizations | High | One good RCT, plus consistent observational studies
Reduction in neurological events | Low | Consistent observational studies
Reduction in transfusion frequency | Insufficient | Few observational studies
Key Question 1 and 2 —Adults
Increase in fetal hemoglobin | High | One good RCT, plus consistent observational studies
Reduction in pain crises | High | One good RCT, plus consistent observational studies
Reduction in hospitalizations | High | One good RCT, plus consistent observational studies
Reduction in neurological events | Insufficient | No studies
Reduction in transfusion frequency | High | One good RCT, plus consistent observational studies
Mortality | Low | Inconsistent observational studies
Key Question 3—Children
Leukemia(MDS/AML/Cytogenetic abnormalities) | Insufficient | CERHR report
Developmental toxicities (in utero) | Insufficient; evidence of harm in animals | CERHR report
Leg ulcers | Insufficient | CERHR report
Growth delays (children 5 to 15 years) | Evidence of no growth delay | CERHR report
Developmental toxicities in next generation | Insufficient | CERHR report
Key Question 3—Adults
Leukemia(MDS/AML/Cytogenetic abnormalities | Low (absence of effect) | Indirect evidence and inconsistent results
Leg ulcers | High (absence of effect) | One good RCT, plus consistent observational studies
Skin neoplasms | Insufficient | No studies in sickle cell; high-grade evidence in other populations
Secondary malignancies | Insufficient | No studies in sickle cell; low-grade evidence in other populations
Adverse pregnancy outcomes | Insufficient | CERHR report
Spermatogenesis defects | Low | Case reports with evidence of causality
Key Question 4—Barriers
Negative provider attitudes are barrier to use of pain medication | High | More than one study, consistent finding
Poor provider knowledge is a barrier to use of pain medication | High | More than one study, consistent finding
Patient sex is not a barrier to use of therapies | Moderate | Few studies, but consistent
Patient/family knowledge is a barrier to use of therapies | Low | Few studies, and inconsistent
Number of hospital visits is a barrier to use of therapies | Low | Few studies, and inconsistent
Patient age is a barrier to use of therapies | Low | Few studies, and inconsistent
Key Question 4—Interventions
Interventions do not improve adherence to therapies for chronic disease management | Low | Small studies, diverse outcome measures
Interventions can overcome barriers to use of pain medications | Moderate | High quality studies, but few
Interventions can overcome barriers to the receipt of routine, scheduled care. | Moderate | High quality studies, but few

RCT = Randomized controlled trial; CERHR = Center for the Evaluation of Risks to Human Reproduction; MDS/AML = myelodysplastic syndromes/acute myelogenous leukemia

## Key Question 3: What are the Short- and Long-term Harms of Hydroxyurea Treatment?

### Report by The Center for the Evaluation of Risks to Human Reproduction (CERHR)

The National Toxicology Program (NTP) and the National Institute of Environmental Health Sciences (NIEHS) established the NTP's CERHR in June 1998. The stated purpose of the CERHR was “to provide an unbiased, scientific evaluation of human and experimental evidence of the adverse effects on reproduction and development caused by agents to whom humans may be exposed.” Hydroxyurea was selected for study by the Center in 2006; we briefly review their findings here, as they are relevant to our review of the toxicities of hydroxyurea. CERHR researchers searched databases that included REPROTOX, HSDB, IRIS, DART, PUBMED, and Toxline, through January 2007, to identify articles pertinent to the evaluation of adverse effects on development and reproduction in both humans and animals. The articles were reviewed in advance by an expert panel, which then prepared a document describing the strength of the evidence that hydroxyurea is a reproductive or developmental toxicant. ^26^ The 13-member expert panel discussed the data and finalized their opinions about the toxicity ofhydroxyurea, identified areas of knowledge gaps, and identified future research priorities. Given this detailed report and acceptable methodology, this EPC opted not to duplicate their effort, and we instead report here a summary of their findings regarding the developmental and reproductive toxicities of hydroxyurea.

#### Scope and findings

Summary of the General Toxicology and Biological Effects of Hydroxyurea. The expert panel concluded, based on a single study, that nursing infants of women taking the drug may have an exposure to hydroxyurea of 1 to 6 mg/day, but that this dose would be dependent on the infant's nursing schedule, the mother's dose, and the volume of the infant's feeds.

Summary of the Developmental Toxicity Data. The panel concluded that hydroxyurea treatment of children aged 5 to15 years does not cause a growth delay. The panel felt that there were inadequate data regarding growth effects in infants and children younger than 5 years of age, as well as insufficient data to allow them to evaluate the effects of the drug on pubertal development. The expert panel also concluded that there were no data on the effects on subsequent generations following exposure of germ cells to hydroxyurea, including exposure during fetal life, infancy, childhood, and adolescence. The CERHR report described no studies of the long-term health effects, including carcinogenicity, from childhood exposure to hydroxyurea. The expert panel found sufficient data to conclude that there is developmental toxicity in rat and mice fetuses that are exposed to hydroxyurea in utero. The manifestations of this toxicity include decreased body weight, increased malformation rate, and a decrease in the number of live births. The expert panel felt that the experimental animal data were relevant to the assessment of risk in humans. Thus, the expert panel had concerns that hydroxyurea may increase the risk of congenital anomalies or abnormalities of fetal growth and postnatal development after exposure of pregnant women to the drug.

Summary of the Reproductive Toxicity Data. The expert panel found no data on the reproductive effects of hydroxyurea in humans. Similarly, the panel concluded that there were insufficient data to be able to draw conclusions about female reproductive toxicity in animals. However, they concluded that hydroxyurea produces reproductive toxicity in male mice, as evidenced by decreased testis weight and sperm count. They also felt that the experimental animal data were relevant to the assessment of risk in humans. Therefore, they expressed concerns about the adverse effect of hydroxyurea on spermatogenesis in men receiving the drug at therapeutic doses.

Summary of Pregnancy Outcomes. The CERHR report identified 21 relevant papers. The report reviewed studies examining pregnancy outcomes in women who had sickle cell disease or essential thrombocythemia and were taking hydroxyurea. However, there were no controlled studies on the use of the drug during pregnancy. The largest case series described outcomes in 32 pregnancies in 31 patients treated with hydroxyurea for essential thrombocythemia (n=22), CML (n=6), chronic myeloid splenomegaly (n=2), or sickle cell disease (n=1). ^94^ The authors concluded that the two cases of intrauterine fetal growth restriction and the nine patients with preterm deliveries constituted an increase over the rates expected for this population, but it was not possible to attribute causality in these cases.

The remaining 20 articles were case reviews or small case series, and there was no clear evidence for causality in the case of any of the 10 abnormal outcomes described in the report. These outcomes were: elective abortion (n=3), stillbirth (n=2), preterm delivery (n=2), intrauterine growth restriction (n=2), and one unknown event. Based on the case series described above and these case reports, the CERHR report concluded that the use of hydroxyurea in pregnancy does not appear to be commonly associated with adverse perinatal outcomes and that there are no data on long-term outcomes in children who were exposed in utero. Given the publication of animal data indicating that hydroxyurea produces congenital anomalies and abnormalities of fetal growth in multiple experimental species, the expert panel did express a concern that hydroxyurea might increase the risk of congenital anomalies or abnormalities of fetal growth and postnatal development after exposure of pregnant women to the drug.

We identified one additional article related to hydroxyurea in pregnancy that was not included in the CERHR report. ^95^ This report was a case series of 21 pregnancies in 18 patients with a hematological malignancy. Only one patient, a 22-year-old woman with CML, received hydroxyurea during her pregnancy. At 28 weeks of gestation, she was admitted for vaginal bleeding, underwent emergency cesarean delivery for placental abruption, and delivered a male infant weighing 1800 grams, with normal hematological values. The patient died on post-operative day 1, and the infant developed respiratory distress and died as a result of intracranial bleeding.

### Results of Randomized Trials in Sickle Cell Disease

The toxicity data reported from randomized trials of hydroxyurea in sickle cell disease have mainly been limited to short-term toxicities. Only four publications from the MSH study reported toxicities in adults. ^21,^ ^39,^ ^40,^ ^43^ The investigators described lower absolute neutrophil counts (4900/μl vs 6400/μl) in the hydroxyurea group than in the placebo group, but both groups had similar numbers of other adverse events, including thrombocytopenia, thrombocytosis, malignancy, aplastic crisis, aseptic necrosis, lymphadenoathy, and bleeding tendency. The proportion of patients with hair loss, fever, rash and/or nail changes, or gastrointestinal disturbance reported at three or more followup visits was similar for both groups (Table 6; Appendix C *, Evidence Table 12). ^21^ The one publication describing long-term followup of the MSH participants described only two malignancies, one in each group. ^43^ In the study of Belgian children, white blood cell counts decreased from baseline by 3570/μl (p<0.001), but changes in the absolute neutrophil count were not reported. ^44^

Table 6 Major Toxicities of Hydroxyurea in Other Diseases

Disease | Total studies: N | Leukemia^†^, n | Leg ulcer, n | Skin neoplasms, n | Secondary malignnancies, n | Comments
HIV | RCT: 6 | 0 | 0 | 0 | RCT: 1 | 4 cases of Kaposis' sarcoma in the retroviral + HU arm, compared to 1 in the arm with retroviral therapy and no HU; this was not statistically significantly different
| Other: 0
CML | RCT: 5 | NA | 0 | RCT: 0 | RCT: 1 | 5/158 patients examined in one study for skin manifestations while on HU had skin cancer;
| Other: 4 | | | Other: 1 | Other: 0 | RCT there were a total of 5 malignancies but no difference between arms in the incidence of malignancy (HU v. IFN v. Bu)
Solid tumor | RCT:2 | 0 | 0 | 0 | 0
| Other: 0
MPD* | RCT: 0 | RCT: 0 | RCT: 0 | 0 | RCT: 0 | One cohort study with a comparison arm: There was no statistical difference in the incidence of AML between those patients treated with HU alone and those who did not receive any drug therapy (p=0.64).
| Other: 5 | Other: 5 | Other:2 | | Other: 1 | An additional 16 cases of leukemia were reported in the remaining observational studies that included a total of 400 patients.
PV | RCT: 1 | RCT: 1 | RCT: 1 | RCT: 1 | RCT: 1 | The actuarial risk of leukemia in the RCT was 10% at 13 years in the HU-alone arm. In the RCT, there was a slight, but not significant, increase in skin cancers for subjects in the HU arm (4 versus 1). In the observational studies with comparison arms, there was no statistical difference in leukemia when HU was compared to arms with no myelosuppresive therapy.
| Other: 5 | Other: 5 | Other: 0 | Other: 0 | Other: 2
ET | RCT: 2 | RCT: 2 | 0 | 0 | RCT: 1 | The RCT showed no significant difference in leukemia incidence between arms. When the patients that had received Bu in the randomized trial were removed from analysis, there was no significant difference in the incidence of malignancies between those treated with HU and the untreated group. In the observational studies, after controlling for other risk factors in multivariate analysis, HU was not associated with a statistically significant increase in the risk of leukemia.
| Other: 4 | Other: 4 | | | Other: 0

* Studies that combined different MPDs

† Number of studies reporting toxicity

HU = hydroxyurea; CML = chronic myelogenous leukemia; MPD = myeloproliferative disorder; PV = polycythemia vera; ET = essential thrombocythemia; IFN = interferon; Bu = busulfan; AML = acute myelogenous leukemia; RCT = randomized controlled trial

### Results of Observational Studies in Sickle Cell Disease Including Case Reports

Observational Studies. Although studies that lack comparison arms are not optimal for attributing causality to an observed event, observational studies are useful for describing events in people exposed to a drug outside of a randomized trial (Table 6; Appendix C, Evidence Table 13). We first describe the observational studies reporting cases of leukemia.

In the observational studies we reviewed, three cases of leukemia were reported in people with sickle cell disease who were treated with hydroxyurea. In a study from the French group, a 10-year-old girl was treated with the drug for 18 months. She was admitted with pain and fever; bone marrow examination disclosed ALL, with the Philadelphia chromosome. ^48,^ ^55^ Thus, this group noted a single case among 225 treated patients in this well-characterized cohort whose investigators paid careful attention to losses to followup. The Belgian group reported on a 21-year-old woman who developed acute promyelocytic leukemia after 8 years of hydroxyurea therapy. ^82^ Researchers for the International Association of Sickle Cell Nurses and Physician Assistants collected data about cancer development in 16,613 patients with sickle cell disease. Cancer was diagnosed in 49 patients, including seven cases of leukemia. Three of the 49 had been using hydroxyurea, including one 14-year-old who developed ALL 3 months after initiation of the drug. There were no data on the prevalence of hydroxyurea use among this population of 16,613 people (Appendix C, Evidence Table 13). ^53^

Another study described a related toxicity, acquired DNA mutations, in hydroxyurea-treated patients with sickle cell disease. ^57^ In this study, two assays were used to quantify acquired somatic DNA mutations in peripheral blood mononuclear cells (PBMCs) after in vivo exposure to hydroxyurea: The HPRT assay measures hypoxanthine phosphoribosyl transferase (HPRT) mutations, while the VDJ assay identifies “illegitimate” T-cell receptor Vγ-Jβ interlocus recombination events. The authors looked at PMBCs from three groups: patients with sickle cell disease who were treated with hydroxyurea, patients with myeloproliferative diseases who had been exposed to hydroxyurea, and normal controls. They found that adults with sickle cell disease and adults with myeloproliferative diseases had a comparable number of mutations when compared to controls; however, children with sickle cell disease having 30 months of hydroxyurea exposure had more VDJ mutations (1.82 +/- 1.2) than did children with 7 months of exposure (1.58 +/- .87) or no exposure at all (1.06 +/- 0.45, p=0.04). HPRT mutations were similar in the two exposed groups. The authors interpreted this result as a slight increase in recombination events and suggested that this increase does not directly portend the development of leukemia. Similarly, 26 adult patients with sickle cell disease who had been exposed to hydroxyurea for at least 5 years at the MTD were found to have no increase in illegitimate VDJ rearrangements, when assessed using similar methodology. ^81^ Karotypic analysis in one study revealed no difference in the percentage of abnormal chromosomes before and after treatment with hydroxyurea. ^46^ In a similar, although smaller study, there was no significant difference in chromosomal aberrations (p>0.05) pre- and post-treatment and no difference in the mitotic index (Appendix C *, Evidence Table 13). ^47^

The more frequent toxicities are described in Appendix C, Evidence Table 13. Toxicities were described in 22 of the 35 observational studies; 8 of these were studies designed to primarily report toxicities from hydroxyurea. ^47,^ ^48,^ ^53,^ ^55,^ ^57,^ ^64,^ ^66,^ ^68^ Additional articles described moderate decreases in platelet counts on therapy; this observation is not included in the table, since this is an known effect of the drug and is generally not considered to be an adverse event. Rare deaths were reported. In one study with 455 patient-years of followup, one child died of pneumococcal sepsis despite a normal absolute neutrophil count, and another child died from an acute transfusion reaction. ^78^ Neither death was thought to be related to hydroxyurea. There were single deaths reported in five other studies^48,^ ^60,^ ^72,^ ^77,^ ^82^; all of the deaths were from expected complications of sickle cell disease, and none were thought to be due to myelosuppression (Appendix C, Evidence Table 13).

Neutropenia was a frequently reported adverse event. In the HUSOFT study, 17 of the 28 children had an absolute neutrophil count of less than 1500/μl, including 6 with an absolute neutrophil count of less than 500/μl. ^60^ In the extension of the HUSOFT study, there were 21 episodes of neutropenia in 10 children in the third treatment year and 21 episodes in 9 patients in the fourth year. ^72^ In the HUG-KIDS study, 56 of 84 patients had an absolute neutrophil count of less than 2000/μl. Thrombocytopenia was less frequently reported.

Leg ulcers were only reported as occurring in three studies and were infrequent. ^55,^ ^66,^ ^74^ Prior leg ulcer was associated with the development of leg ulcer during hydroxyurea treatment in the study that reported the highest incidence of ulcers (5 of 17 treated patients). ^66^ Rash and nail changes were moderately common.

The other even rarer toxicities are described in Appendix C, Evidence Table 14. The number of individuals experiencing these toxicities was low in all studies. No study reported any secondary malignancies.

Case Reports. We identified 19 published case reports about toxicities associated with hydroxyurea use in patients with sickle cell disease (Appendix C, Evidence Table 15). Two of these reports described the same Greek child who developed Hodgkin's lymphoma. ^96,^ ^97^ The 18 unique case reports included four reports of low sperm count or decreased sperm motility, two cases of avascular necrosis, two cases of skin hyperpigmentation, and one case each of leg ulcer, cytopenia, splenomegaly, cryptosporidium infection, intracerebral hemorrhage, acute myocardial infarction, and the case of Hodgkin's lymphoma previously mentioned. All of these toxicities were described in adults, except for the case of Hodgkin's.

In addition, leukemia was reported in three young women with sickle cell anemia who had been treated with hydroxyurea. We describe these three cases in detail here: One was the 21-year-old woman mentioned above who was treated as part of the Belgian Registry of Sickle Cell Disease. ^98^ She had been taking hydroxyurea for 8 years but stopped for 2 years while pregnant and nursing. She resumed hydroxyurea therapy, and 8 months later was diagnosed with AML (M3v). Another report was of a 25-year-old Saudi Arabian woman who was treated with hydroxyurea for 2 years with good response. She was subsequently diagnosed with AML ( FAB M1); cytogenetic studies revealed no abnormal clone. ^99^ Interestingly, this patient had splenomegaly, without explanation, at the time that she began hydroxyurea therapy and also had hepatitis C infection. The final case report described a 42-year-old woman with Hb SS who was treated for 6 years with hydroxyurea. She was diagnosed withAML; she had no cytogenetic analysis. ^100^ We are aware of one other case report of leukemia in a patient with sickle cell anemia treated with hydroxyurea. This case was reported in abstract form and described a 27-year-old woman who developed an acute non-lymphocytic leukemia after 8 years of hydroxyurea therapy. Her bone marrow aspirate suggested that the leukemia developed in the setting of myelodysplasia. ^101^

Each of these toxicities had only Level 3 evidence for causality (at least one “possible” report of an adverse event, but no “certain” or “probable” case report), with the exception of cytopenia, which was considered to have Level 2 evidence (at least one “probable” report of an adverse event, but no “certain” report) because there was one case report that demonstrated probable causality. Reports of leukemia are difficult to score with the WHO causality scale because there is no possibility for regression of disease with removal of the putative causal agent (leukemia cannot spontaneously remit), so the case reports of leukemia cannot be described as showing probable or certain causality.

### Results of Studies of Other Diseases

Given that the number of patients with sickle cell disease who were treated for long durations with hydroxyurea is few, we opted to review toxicities in patients with diseases other than sickle cell disease in order to gather additional evidence regarding the potential toxicities of this drug.

Randomized trials and large observational studies. We found 39 publications (20 randomized and 19 observational studies) that examined the toxicity of hydroxyurea in diseases other than sickle cell disease. (Appendix C *, Evidence Tables 16, 17, 18, 19, 20, and 21). Included among these were studies of the addition of hydroxyurea to other often-used therapies, enabling us to describe the additive toxicity attributable to hydroxyurea. These publications included studies examining the effects of adding hydroxyurea to standard antiretroviral therapy in patients with HIV/AIDS and the addition of hydroxyurea to interferon, as these drugs may be used in patients with sickle cell disease and comorbid illnesses. There were eight publications about hydroxyurea use in patients with HIV, nine in patients with CML, five in patients with a variety of myeloproliferative diseases, two in patients with solid tumors, eight in patients with polycythemia vera, and six in patients with essential thrombocythemia. We present the results for the RCTs, followed by those for the observational studies.

Description of the quality of the studies. The quality of the RCTs was evaluated using the Jadad criteria. The study scores ranged from 1^102,^ ^103^ to 4^104^ (Appendix C, Evidence Table 22), with most of the studies scoring a 2 or 3. The studies were all randomized, but most did not describe the method of randomization, and they also lost points for not describing the blinding of the participants. A majority of the studies also provided at least some information about the subjects that were withdrawn from the study.

The observational studies were evaluated with our 16-point scale for assessing the quality of these studies. These studies received between 28 percent ^105^ and 73 percent^106^ of the available points (Appendix C, Evidence Table 23). Thus, none of these studies reached our cutoff of more than 80 percent, which we judged to indicate high quality. Only one of these studies reported on adherence. ^107^ The scores were also diminished because most of them did not describe the subjects that were lost to followup.

#### Scope and findings

HIV/AIDS. The eight publications related to HIV examined the addition of hydroxyurea to antiretroviral therapy in randomized trials. The number of patients per arm of the study ranged from 21 to 72. The addition of hydroxyurea to other antiretroviral therapy was associated with a significantly increased risk of neutropenia and thrombocytopenia in two of the three studies in which this toxicity was reported. ^102,^ ^104,^ ^108^–^110^ Three of the publications described the same patient cohort. ^102,^ ^109,^ ^110^ None of these studies, however, examined the exact same drug regimen. In the study by Frank et al., ^104^ the thrombocytopenia was seen only in the group on the high dose of hydroxyurea (1500 mg/day). Two studies showed that the addition of the drug increased the risk of gastrointestinal (GI) upset. ^110,^ ^111^ Swindells et al. demonstrated that about twice as many patients on hydroxyurea had neurological or psychiatric issues and endocrinological or metabolic side effects, when compared to patients receiving an antiretroviral agent alone. ^111^

The cluster of papers by Rutschmann et al. included three papers with results from three different time points for the same 144 randomized study patients. ^102,^ ^109,^ ^110^ Twenty-four patients crossed over to hydroxyurea after 12 weeks, and 19 remained in the non- hydroxyurea arm. This series of studies demonstrated a significant increase in fatigue, paraesthesias, and neuropathy in the treatment arm with hydroxyurea added to ddI/stavudine, when compared to the arm with antiretroviral therapy alone. The maximum followup was 24 months (range, 24 weeks to 24 months). This is the only study that reported any incidence of malignancy. There were four cases of Kaposi's sarcoma in the hydroxyurea arm, as compared to one case in the non-hydroxyurea arm (p=0.2). There were no reports of leukemia in any of these studies.

There were no observational studies of hydroxyurea use in HIV treatment that met our inclusion criteria.

Chronic Myelogenous Leukemia (CML). There were five randomized trials of hydroxyurea use in CML. In these studies, hydroxyurea was compared to interferon, to the combination of hydroxyurea and interferon, and to busulfan. The number of patients per arm ranged from 24 to 308. The maximal followup for these studies was approximately 4 years. There were three articles from the German CML group. ^112^–^114^ The first of these articles compared hydroxyurea with busulfan in 441 patients. ^112^ The median followup was 2 years. Patients were allowed to cross over to the other arm of the study, depending on their response. Little toxicity was reported in this paper, although the authors noted that there was less bone marrow aplasia and lung fibrosis in the hydroxyurea arm, and they felt that hydroxyurea was better tolerated than busulfan. The second study from the German CML group enrolled 513 patients in three arms: hydroxyurea versus interferon versus busulfan. ^113^ The median followup in this study was 3.4 years. Eighteen percent of the patients on interferon had an adverse effect that required discontinuation of therapy, as did 10 percent in the busulfan group and only 0.5 percent in the hydroxyurea group. The authors reported the development of five malignancies, one in the hydroxyurea arm and two each in the interferon and busulfan arms. Most differences in toxicities were seen in the final German study, which followed patients for over 7 years. ^114^ This study compared outcomes in 534 patients treated with either hydroxyurea alone or with hydroxyurea and interferon. There was more dermatologic, gastrointestinal, and bone marrow aplasia in the interferon plus hydroxyurea arm than in the hydroxyurea-alone arm (no p values given). This study and the one by the Benelux Chronic Myelogenous Leukemia Study Group^115^ also showed increased flu-like and psychiatric illness in the interferon plus hydroxyurea arm. No secondary malignancies were reported in either of these studies or in an additional small study comparing hydroxyurea and interferon. ^116^ The studies did report progression to blast crisis, since this was considered an outcome and not a toxicity.

To help address the question of the possible association between hydroxyurea and the risk of malignancy, we included a case series of 26 patients with AML who had a unique t(3;21) chromosomal translocation. ^117^ This group included 15 patients with CML who had been treated with hydroxyurea, along with one patient with CML who had received imatinab. Another six of the patients with AML had received a mixture of prior chemotherapies for other malignancies prior to developing AML, and two patients had de novo AML and had no prior chemotherapy exposure. The patients treated with hydroxyurea had been on therapy for 2 weeks to 31 months before progressing to AML.

There were two additional case series involving patients with CML. One of these was an evaluation of skin manifestations in 158 patients treated with hydroxyurea for a median of 38 months. ^118^ Thirteen percent of the patients developed skin toxicity while on the drug, and five patients developed skin cancer. The racial makeup of the patients in this study was not reported. The other case series examined the effectiveness of hydroxyurea in 134 patients with CML and mentioned only minor adverse effects in a total of 3 patients. ^119^ The final observational study in CML was a cohort study comparing hydroxyurea to busulfan for treating CML. ^120^ The median duration of followup in this study was 32 months for hydroxyurea and 31 months for busulfan. There was no mention of the development of secondary malignancies in either the busulfan- or hydroxyurea-treated patients in this publication.

Solid Tumors. There were two controlled trials of hydroxyurea use in patients with solid tumors. ^121,^ ^122^ In a study of hydroxyurea versus adriamycin use in advanced prostate cancer, more patients in the hydroxyurea arm developed leukopenia (no p values were given). ^121^ We found no observational studies of hydroxyurea use for the treatment of solid cancers.

Polycythemia Vera. There were two publications describing randomized trials involving polycythemia vera, ^103,^ ^123^ both of which were part of the same large trial by Najean et al. comparing hydroxyurea and pipobroman. The first trial reported on subjects who were treated from 1 to 17 years. ^123^ The second study reported toxicities after subjects had a mean exposure of 14 years to hydroxyurea and of 11 years to pipobroman. ^103^ The first study did not report leukemia incidence by arm but reported an actuarial risk of 10 percent at 13 years for both arms. The second study described 15 subjects in the hydroxyurea arm who developed leukemia, with 40 percent of the disease occurring after the 12th year of followup; in the pipobroman arm, 25 subjects developed leukemia, with 44 percent of the disease occurring after the 12th year of followup. Only the first publication reported the incidence of other malignancies. The hydroxyurea arm had 10 subjects with malignancies, with an incidence of 1.1 percent per year; in the pipobroman arm, there were 6 subjects who developed a malignancy, with an incidence of 1.1 percent per year. The authors noted a slight, but not significant, increase in skin cancers among subjects in the placebo arm (four versus one).

There were six observational studies examining the outcomes of patients with polycythemia vera. The largest of these studies described 1,638 patients who were followed for a median of 2.8 years (maximum, 5.3 years). ^124^ In this study, three treatment groups were described: (1) those treated with hydroxyurea, (2) those treated with any other cytoreductive drug alone or in combination, and (3) those treated with no drug or α-interferon alone. Twenty-two cases of myelodysplastic syndrome (MDS)/AML occurred in these patients at a median of 8.4 years (range, 2.2–19.8 years) after the diagnosis of polycythemia vera. There were 6 cases in the hydroxyurea-alone arm, 11 cases in the other cytoreductive arm, and 5 in the no drug/interferon arm. As compared to patients treated with phlebotomy or interferon, patients receiving hydroxyurea as the only cytoreductive drug had no increased risk of developing MDS/AML, whereas those treated with pipobroman, busulfan, chlorambucil, or ^32^P alone or in combination were at significantly higher risk (hazard ratio [HR], 5.46; 95% confidence interval [CI], 1.84–16.25; p=0.0023). Patients in this study who received hydroxyurea plus alkylating agents or ^32^P had a significantly increased risk of developing MDS/AML (HR, 7.58; 95% CI, 1.85–31.00; p=0.005) when compared to patients treated with phlebotomy or interferon. This study also examined other associations with an increased risk of developing MDS/AML. The authors found that women were at increased risk of progressing to MDS/AML, after controlling for age and drug exposure (HR, 2.93; 95% CI, 1.18–7.26; p = 0.0205), and low blood cholesterol levels at recruitment were associated with progression to MDS/AML (HR, 6.58; 95% CI, 2.08–20.86; p = 0.0014).

The second-largest cohort study involving polycythemia vera had 597 patients. ^105^ These patients were analyzed in four treatment groups; (1) hydroxyurea alone, (2) pipobroman, (3) ^32^P and hydroxyurea maintenance therapy, and (4) ^32^P without hydroxyurea maintenance. The patients treated with ^32^P had longer followup than those in the other groups receiving pipobroman or hydroxyurea alone (10.5 years vs 6.7 years, respectively). The rate of MDS/AML or lymphoma was 19 percent after 10 years for the ^32^P arm receiving maintenance hydroxyurea, versus 10 percent at 10 years for the ^32^P arm without hydroxyurea maintenance. This difference was reported as significant, but no p-value was given. In the other two arms, the actuarial incidence of MDS/AML or lymphoma was estimated at 13 percent in the hydroxyurea-alone arm and 14 percent in the pipobroman arm, but the authors noted that few patients had actually been followed for more than 10 years. The authors also reported the actuarial risk of developing a malignancy. The actuarial risk of malignancy for the ^32^P group who received maintenance hydroxyurea was 29 percent at 12 years of followup; it was 15 percent at 12 years for those who received ^32^P but no hydroxyurea maintenance. The actuarial risk for malignancy in the other two arms could not be calculated, but the observed risk was 9 percent in each of the two arms. Finally, this study examined the actuarial risk of developing myelofibrosis. The risk did not differ for the arm receiving ^32^P with maintenance versus the arm receiving ^32^P without maintenance (16 percent at 10 years and 23 percent at 14 years, vs 10 percent at 10 years and 19 percent at 14 years). No patients in the pipobroman arm developed myelofibrosis, and the actuarial risk in the hydroxyurea-alone arm was 17 percent at 12 years. The authors did not feel they could conclude much about the long-term effect of hydroxyurea alone in this study, given the short period of followup. This study was not analyzed by intention to treat. The authors justified the lack of such analysis by stating that in their experience “intended treatment is modified in more than 3/4 of cases before the tenth year, so that actuarial “intention to treat” analysis is probably not valid in the long-term.” They felt that by excluding patients who might have switched therapy from their analysis of long-term followup data, they might remove those patients at the highest risk of a poor outcome. In their study, for example, 12 patients originally assigned to the hydroxyurea arm were switched to pipobroman, and five patients on the pipobroman arm were switched to the hydroxyurea arm.

There were two articles in this series that described outcomes in the same set of patients. ^125,^ ^126^ The original publication^125^ in 1986 compared the outcomes in 51 patients with polycythemia vera who had been treated with hydroxyurea and phlebotomy in the Polycythemia Vera Study Group 08 study (PVSG-08), and they compared this group to a historical control group from the PVSG-01 study in which 134 patients were treated with phlebotomy alone. The maximum followup in this study was 389 weeks (7.5 years). Three patients (5.9 percent) in the hydroxyurea /phlebotomy arm developed leukemia, as compared to two (1.5 percent) in the phlebotomy group (p=0.25). The authors concluded from this original study that this drug did not increase the risk of leukemia at followup of 378 weeks. The followup study by Fruchtman et al. extended the followup of these patients to a median of 8.6 years and a maximum of 15.2 years. ^126^ The incidence of AML in the hydroxyurea /phlebotomy arm was 9.8 percent and 3.7 percent in the control arm; this difference was not statistically significant (p=0.0973). Thirty-one percent of the patients in the hydroxyurea arm died, as compared to 40 percent in the control arm (p=0.07).

Another study that looked at outcomes in patients with polycythemia vera was a study in which the authors compared outcomes in patients treated with hydroxyurea who had received prior myelosuppressive therapy and those in patients treated with hydroxyurea who had not received any prior drug treatment. ^127^ Followup for this study ranged from 15 months to 48 months. There were no statistically significant differences in the incidence of AML between the two groups.

Another observational study was a description of a single-center experience with 100 patients with polycythemia vera who had been treated with hydroxyurea over a 20-year period. ^128^ The mean duration of therapy was 64.9 months (5.4 years). Two patients developed AML, one patient with a 100 pack-year smoking history developed lung cancer, and six patients developed myelofibrosis.

Essential Thrombocytosis. Of the three randomized studies evaluating the use of hydroxyurea in essential thrombocytosis, two were from the same clinical trial. This study compared hydroxyurea to no myelosuppressive therapy. The original publication by Cortelazzo et al. did not report toxicity. ^129^ In the 6-year followup study, ^130^ seven subjects in the hydroxyurea arm developed a malignancy (four MDS/AML, one chronic lymphocytic leukemia, two lung cancers), as compared to one patient (breast cancer) in the no-treatment arm. There was a significant difference in cancer-free survival (p=0.0321). Of note, five of the eight patients with secondary malignancies had received busulfan as cytoreductive therapy before randomization into this study. When the patients who had received busulfan were removed from the analysis, there was no significant difference in the incidence of malignancies between those treated with hydroxyurea and the untreated group. One additional trial was a study of over 800 patients randomized to either hydroxyurea and aspirin or anagrelide and aspirin. ^131^ After a median of 39 months of drug exposure, there was no statistical difference in the incidence of leukemia between the two groups. There was a significantly higher number of patients who developed myelofibrosis in the anagrelide arm than in the hydroxyurea arm (p=0.01), but there was no difference between the two groups in the number of subjects who died from progression of their disease.

There were four observational studies that examined the outcome of patients with essential thrombocytosis. The largest of these studies included 605 patients followed for a median of 84 months (range, 0–424). ^106^ This study looked at the incidence of leukemic transformation and described the study participants in six treatment groups that are outlined in Appendix C, Evidence Table 21. Leukemic transformation occurred in a total of 20 patients (3.3 percent). Five patients in the hydroxyurea-alone arm developed leukemia, as compared to four in the no-treatment arm. In multivariate analyses, older age, abnormally low hemoglobin, and a platelet count greater than or equal to 1000 ×10^9^/l were predictors of leukemic transformation. In univariate analysis, the incidence of leukemic transformation was highest among those receiving cytotoxic therapy (p=0.03). However, there was not a significant risk associated with any therapy in multivariate analysis after controlling for the risk factors identified in prior analysis (p=0.15).

A study published in 1998 reported the outcomes of 357 patients with essential thrombocytosis who had been treated with therapies that included hydroxyurea, ^32^P, pipobroman, and busulfan. ^132^ The median followup was 98 months. Seventeen patients developed MDS/AML or lymphoma. There were no differences in the incidence of MDS/AML or lymphoma between groups when the drugs were used as single agents. However, progression to MDS/AML was less frequent in patients treated with hydroxyurea alone (7 of 201) than in patients treated with hydroxyurea combined with other agents (7 of 50, p =0.01), or than in patients in whom hydroxyurea was used after one of the other agents (3 of 76, p = 0.04). Of the 13 evaluable patients, 7 had 17p deletional chromosomal abnormalities when they developed MDS/AML or lymphoma. All of them had received hydroxyurea either alone (n=3) or in combination with other drugs (n=4).

One study looked at the outcomes of 231 Chinese individuals with essential thrombocytosis over a median followup of 10 years. ^133^ Five patients developed leukemia; three of these patients had been treated with hydroxyurea alone, and two had been exposed to hydroxyurea and melphalan. The use of melphalan was significantly associated with the development of leukemia (p=0.002). Seven patients developed myelofibrosis, six in the hydroxyurea-alone group and one in the hydroxyurea /melphalan group.

The final observational study of essential thrombocytosis was a retrospective analysis of 155 patients treated for essential thrombocytosis in Pavia, Italy from 1985-1995. ^107^ The median followup was 104 months (8–240). In this study, 4 of 23 patients treated with hydroxyurea, 4 of 106 patients treated with pipobroman, and none of the 26 patients who received no therapy developed MDS/AML. The incidence rate ratio for progression was 6.15 for hydroxyurea versus pipobroman (p=0.019). Of note, three of the patients who developed MDS/AML or lymphoma while on hydroxyurea had 17p deletional chromosomal abnormalities.

Myeloproliferative Disorders. The first study we describe was a cohort study comparing several patient populations listed in Appendix C, Evidence Table 19. ^134^ The mean followup period in this study for any patient on hydroxyurea was 7.8 years. Thirteen patients developed MDS/AML or lymphoma, including five patients treated with hydroxyurea alone, seven patients treated with hydroxyurea plus another agent, and one patient that had not received any chemotherapy. There was a significantly increased risk of MDS/AML or lymphoma in the group of patients who received hydroxyurea (either alone or in combination with other agents) when compared to those who were not exposed to any chemotherapy (p=0.033). There was no statistical difference in the incidence of AML or lymphoma between those patients treated with hydroxyurea alone and those who did not receive any drug therapy (p=0.64) Another study was a prospective cohort study that began in 1976 and followed patients with polycythemia vera, essential thrombocytosis, and idiopathic myelofibrosis, all treated with hydroxyurea. ^135^ All patients were followed for at least 5 years. Three of 30 patients with polycythemia vera, 1 of 10 with essential thrombocytosis, and 3 of 10 with myelofibrosis developed MDS/AML or lymphoma. Four of 11 patients with polycythemia vera, 1 of 5 with essential thrombocytosis, and 2 of 3 with myelofibrosis developed chromosomal abnormalities; none of these patients had had any chromosomal abnormalities prior to therapy.

There were two studies that examined outcomes in patients with a variety of myeloproliferative disorders. The first followed 152 polycythemia vera or essential thrombocytosis patients on hydroxyurea for a median duration of 4.3 years. ^136^ In this study, three patients (1.97 percent) developed MDS/AML or lymphoma, and four (2.6 percent) developed leg ulcers. In a retrospective study of 75 patients with essential thrombocytosis and 54 with polycythemia vera treated with hydroxyurea and followed for a median of 7.18 years, three patients developed AML or lymphoma, and one developed pancreatic cancer. ^137^ All four of these patients had received treatment with busulfan prior to therapy with hydroxyurea. In addition to these toxicities, four patients developed leg ulcers, three developed skin rashes, and two developed significant anemia. The final study we reviewed examined the outcomes of 34 patients with polycythemia vera who had been treated with hydroxyurea, 30 with essential thrombocytosis who had been treated with hydroxyurea, 1 with polycythemia vera who had been treated with busulfan, and 4 with essential thrombocytosis who had been treated with interferon. Of the 34 polycythemia vera patients treated with hydroxyurea for a mean of 86 months, 2 (5.7 percent) developed AML or lymphoma. Of the 30 essential thrombocytosis patients exposed to hydroxyurea for a mean of 79 months, 1 developed AML or lymphoma.

Case Reports. We identified 235 case reports in 175 publications. The underlying conditions in the patients experiencing toxicities may have merely reflected the relative proportions of patients taking hydroxyurea, with the proportions of patients having CML or essential thrombocythemia being highest, despite a lack of FDA approval of this drug for the treatment of essential thrombocythemia (Appendix C, Evidence Table 24).

The most frequently reported complication was leg ulcer (66 reports), followed by dermatologic changes (34 reports), including hyperpigmentation, rashes consistent with dermatomyositis, and others. There were 27 reports of skin neoplasms, including epitheliomas, actinic keratoses, basal cell cancers, and, most frequently, squamous cell cancers. Nail changes were also frequently reported (nine case reports). There was one report of alopecia and six reports of oral ulcers or Behcet's disease. Level 1 evidence supports a causal role for hydroxyurea in leg ulcers and in skin neoplasms.

Fever was also a frequently reported event (15 reports), with Level 1 evidence to support a role for hydroxyurea. Similarly, there was Level 1 (at least one “certain” case report of an adverse event) evidence to support a role for this drug in causing hepatitis (often accompanied by fever). The reported pulmonary complications included two reports of alveolitis, with Level 2 evidence supporting causality; one report of pulmonary fibrosis with only Level 3 evidence; and five reports of interstitial pneumonitis, with Level 1 evidence, supporting the causality of hydroxyurea in this complication.

Leukemia was reported 33 times. Among the patients developing leukemia, 57 percent had essential thrombocythemia, 24 percent had polycythemia vera, 6 percent had an MPD, and 6 percent had a hypereosinophilic condition. The mean age of these patients was 32 years (range, 43 to 87 years), and 45 percent were female. The mean length of of hydroxyurea treatment was almost 6 years, with a range of 12 weeks to 17 years. As discussed above, it was impossible to describe the causality as being certain or probable in this scoring system, given a condition that cannot regress.

The other toxicities with Level 1 evidence included azospermia or a decrease in sperm motility, limbal stem cell deficiency (a corneal condition), and pruritis.

Predictors of toxicity. Few studies specified what factors predicted toxicity from hydroxyurea (Table 7). In the MSH trial, the patients having the greatest response in terms of Hb F% were more likely to have two or more episodes of hematological toxicity, ^40^ although it may be the case that hematological toxicity was predicting the Hb F response. The few other findings we noted were that leg ulcers at baseline were associated with leg ulcers while on therapy, ^66^ and viral-like infections were associated with neutropenia while on hydroxyurea. ^60^ As described above, patients with Hb SC disease tolerated dose increases less well than did patients with other genotypes. ^81^ Charache et al. found no association between hydroxyurea clearance and toxicity. ^46^

Table 7 Predictors of Toxicity from Hydroxyurea in Studies of Sickle Cell Disease

Author, year | Predictors of toxicity
Trials
Steinberg, 1997^40^ | Patients with higher Hb F response were more likely to have two or more episodes of hematological toxicity
Observational Studies
Bakanay, 2005^51^ | Lower Hb and higher BUN, 2 BAN alleles, and 1 CAM allele are predictive of being in the deceased group on multivariate analysis
Wang, 2001^60^ | Presumed viral infections associated with neutropenia while on HU
Charache, 2992^46^ | HU clearance was not predictive of toxicity.
Chaine, 2001^66^ | Prior history of leg ulcer was associated with leg ulcer on treatment (p<0.005).

Hb = hemoglobin; HU = hydroxyurea; BUN = blood urea nitrogen

The strength of the evidence regarding the toxicity of hydroxyurea. As described in the Methods, we reviewed the CERHR report as part of our assessment of developmental toxicities. Based on this panel's findings, we concluded that there was insufficient evidence to comment on the risk of leukemia in children treated with hydroxyurea or to conclude that this drug contributes to developmental toxicities in the next generation (offspring of treated patients). Similarly, there was insufficient evidence to allow us to assess whether exposure in utero causes developmental defects, although there was low-grade evidence that the use of hydroxyurea in pregnancy is not commonly associated with adverse perinatal outcomes. There was low-grade evidence, including the efficacy studies that we reviewed, that hydroxyurea is not associated with growth delays in children and adolescents. The CERHR report stated that the animal data, which were reviewed for their report, are relevant to humans, and the panel found evidence of developmental toxicities in rats and mice exposed in utero.

We graded separately the evidence regarding toxicities of hydroxyurea in adults in the case of patients with sickle cell disease and those with other diseases. We used the evidence from other diseases as indirect evidence regarding toxicities that could be potentially expected in patients with sickle cell disease.

Low-grade evidence based on the results of the MSH suggested that hydroxyurea treatment in adults with sickle cell disease is not associated with leukemia. The evidence from patients with other diseases also provided low-grade evidence that the drug is not associated with leukemia. High-grade evidence supported that hydroxyurea is not associated with leg ulcers in patients with sickle cell disease, although high-grade evidence supported the claim that it is associated with leg ulcers in patients with other conditions. The evidence was insufficient in sickle cell disease to indicate whether hydroxyurea contributes to skin neoplasms, although high-grade evidence in other conditions supported the possibility that it does. Similarly, there was insufficient evidence to indicate whether hydroxyurea is associated with secondary malignancies in adults with sickle cell disease, and the evidence in other diseases was only low-grade. There was also insufficient evidence regarding pregnancy outcomes in treated patients with sickle cell disease, and the evidence from patients with other diseases was low-grade but supported a lack of adverse effects. Low-grade evidence supported the possibility that hydroxyurea is associated with spermatogenesis defects in patients with sickle cell disease, and this relationship was supported by low-grade evidence from other conditions (Table 5).

## Key Question 4. What are the Barriers to the Use of Hydroxyurea Treatment (and other therapies) for Patients who have Sickle Cell Disease and what are the Potential Solutions?

### Characteristics of Studies Addressing Barriers to the Use of Therapies for Sickle Cell Disease

Of the studies that addressed this key question, 15 employed a cross-sectional study design to test an association between a patient, provider, or system factor and the use of therapy; ^138^–^152^ 18 described patient and/or provider-reported barriers to therapy; ^93,^ ^153,^ ^153^–^168^ and 3 used both methods. ^155,^ ^169,^ ^170^ Studies employing cross-sectional designs to assess the association between a patient, provider, or system factor and the use of therapies are shown in Appendix C *, Evidence Table 25, and studies describing patient and/or provider-reported barriers to therapy are shown in Appendix C, Evidence Table 26.

Cross-sectional studies testing associations. Of the 18 studies using a cross-sectional design (Appendix C, Evidence Table 25), only 1 addressed barriers to the use of therapies to increase Hb F, ^138^ 8 addressed barriers to the use of established therapies for management of sickle cell disease, ^139^–^144,^ ^169,^ ^170^ 3 addressed barriers to the use of appropriate pain medication during vaso-occlusive crises, ^145,^ ^146,^ ^155^ and 6 addressed barriers to the use of routine, scheduled care for sickle cell disease. ^147^–^152^

The one study that dealt with therapies to increase Hb F examined factors associated with patient (or parent) decisions to initiate therapy. ^138^ Of the eight studies that addressed barriers to the use of established therapies, one focused on patient adherence to chelation therapy, ^139^ while the remainder focused on patient adherence to antibiotic prophylaxis. ^140^–^144,^ ^169,^ ^170^ Of the three studies that that dealt with the use of appropriate pain medications during vaso-occlusive crises, two addressed providers' provision of pain medications to patients, ^145,^ ^155^ and one addressed patients' use of pain medications. ^146^ Of the six studies that dealt with routine, scheduled care, three directly addressed the use of routine health services, ^147,^ ^148,^ ^150^ one addressed the transition to adult care, ^149^ one addressed appointment-keeping, ^152^ and one addressed general adherence. ^151^

Two-thirds of the cross-sectional studies were published in the past 5 years (2002-2007), while the remainder were published in the previous decade (1992-2001). Three of the 18 cross-sectional studies focused on health professionals as study subjects, ^140^ ^145,^ ^155^while the remainder studied patients. Adult patients with sickle cell disease were the targeted patient population of interest in only 1 of the 18 cross-sectional studies. ^152^ In four of the cross-sectional studies, children and adults were the targeted patient population of interest.^147,^ ^149,^ ^150,^ ^155^ The remainder focused on children (or parents/caregivers). The majority were conducted in the United States, while one was conducted in Saudi Arabia^170^and five did not specify a location.

Descriptive studies of reported barriers. Of the 20 descriptive studies of patient- and provider-reported barriers to the use of therapies for sickle cell disease (Appendix C, Evidence Table 26), 1 addressed barriers to the receipt of treatment to increase Hb F, ^93^ 2 addressed barriers to patient adherence to established therapies for disease management, ^169,^ ^170^ 13 addressed barriers to the receipt of pain medications, ^153^–^155,^ ^159^–^168^ 1 addressed barriers to bone marrow transplantation, ^158^ and 3 addressed barriers to generic healthcare quality. ^156,^ ^157,^ ^171^

About half of the descriptive studies were published in the past decade (1998-2007), with the remainder published in the preceding decade (1988-1997). Most (n=13) descriptive studies occurred in the United States; however, 6 were conducted in the United Kingdom, ^154,^ ^159,^ ^161,^ ^163,^ ^166,^ ^168^ and one was conducted in Saudi Arabia. ^170^

Of the 20 descriptive studies, 9 used primarily quantitative descriptive methods (e.g., questionnaires), ^93,^ ^153^–^158,^ ^169,^ ^170^ 10 used primarily qualitative methods (e.g., focus groups and in-depth individual interviews), ^153,^ ^159^–^167^ and 1 used mixed quantitative and qualitative methods. ^168^ The majority of the descriptive studies included patients as a study population, ^154,^ ^158,^ ^159,^ ^161,^ ^162,^ ^164^–^167,^ ^169,^ ^170^ while others included providers, ^93,^ ^155^–^158^ and some included both patients and providers. ^160,^ ^163,^ ^168,^ ^171^ Of the 15 descriptive studies that included patients as the study population, 12 were focused on adults, ^154,^ ^159^–^168,^ ^171^ and 3 were focused on children. ^158,^ ^169,^ ^170^

### Results of Studies Addressing Barriers to the Use of Therapies for Sickle Cell Disease

Results of cross-sectional studies testing associations. The results of the cross-sectional studies are summarized in Table 8. Each of the potential barriers and facilitators below was identified in only one study. The factors in each category that were examined but not associated with use of therapies are included in Table 8 but not detailed below.

Table 8 Patient, Provider, and Societal Barriers and Facilitators Shown to be Associated with Treatment for Patients with Sickle Cell Disease

| | Barriers and Facilitators (n Studies)
Type of Treatment | | Patient | Provider | Societal/System
Treatments to increase hemoglobin F | Barriers | | NR | NR
| Facilitators | Perceived efficacy (1) | NR | NR
| | Perceived safety (1)
| Neither | Parental age (1) | NR | NR
| | Parental sex (1)
| | Number of children (1)
| | Parent's rating of child's HRQOL (1)
| | Frequency of VOC (1)
Established therapies for disease management | Barriers | Family stress (1) | NR | Academic medical setting (1)
| | More children at home (1)
| Facilitators | Private insurance (2) | Provider knowledge (1) | NR
| | Caregiver knowledge (2) | Provider specialty [pediatrics] (1)
| | Parent and child share responsibility (1)
| | Hospital visits (1)
| | More adults in home (1)
| | Having a car (1)
| | No prior child history of transfusions (1)
| | Younger patient age (1)
| | Intent to adhere (1)
| | Perceived benefits (1)
| | Family employment (1)
| Neither | Behavioral/psychological adjustment (1) | Provider years in practice (1) | Convenience of the regimen (1)
| | Patient/caregiver knowledge (2) | Provider gender (1) | Cost sharing (1)
| | Satisfaction with regimen (1)
| | Patient sex (3)
| | Patient age (3)
| | Urban residence (1)
| | Non preventive outpatient care visits (1)
| | Parental education (1)
| | SCD type (1)
| | Number of children (1)
| | Years on therapy (1)
| | History of stroke (1)
| | Hospital visits (2)
| | Established therapies for disease-management
| | Child cognitive disability (1)
Pain management during vaso-occulsive crisis | Barriers | Hospital visits (1) | Negative attitudes (1)
| Facilitators | Dispositional optimism (1) | Female sex (1) | NR
| | | Fewer years in practice (1)
| Neither | Patient age (1) | Provider attitudes (1) | NR
| | Patient sex (1) | Professional experience and training (1)
| | Parental education (1)
Receipt of routine scheduled care | Barriers | Greater community socioeconomic distress (1) | NR | NR
| Facilitators | Greater parental/family knowledge (2) | NR | NR
| | Rural geographic region* (2)
| | Self-efficacy (1)
| | Female patient sex (1)
| | Family problem-solving effort (1)
| | Higher family income (1)
| | Illness-related stress (1)
| | Social support (1)
| Neither | Community socioeconomic distress (1) | NR | Distance to a clinic (2)
| | Physical functioning (1)
| | Number of medical problems (1)
| | Parent adolescent relationship (1)
| | Disease severity (1)
| | Stressful life events (1)
| | Clinical mal-adjustment (1)
| | Receipt of preparation for the transfer to adult care (1)
| | Interference of disease in daily life (1)
| | Level of medical problems (1)

* After adjustment for distance to clinic. Bivariate results in one of the two studies suggested that rural patients have less utilization when travel distance is not controlled.

VOC = vaso-occlusive crisis; SCD = sickle cell disease; NR = not reported.

The one study that addressed barriers to the use of therapies to increase Hb F (specifically, hydroxyurea) found that the perceived efficacy and perceived safety of hydroxyurea had the largest influence on patients' (or parents') choice of hydroxyurea therapy over other therapies. ^138^

The eight studies that addressed potential barriers to the use of established therapies for disease management found two potential patient-related barriers (family stress and having more children in the home), and one potential system-related barrier (being seen in an academic medical center). ^139^–^144,^ ^169,^ ^170^ These eight studies also identified 11 potential patient-related facilitators of the use of established therapies for disease management (private insurance, sharing of responsibilities between parent and child, more hospital visits, more adults in the home, having a car, no child prior history of transfusion, younger patient age, more caregiver knowledge, greater intent to adhere, greater perceived benefits, and family employment) and two potential provider-related facilitators (provider female gender and pediatric specialty).

The three studies that addressed barriers to the use of appropriate pain medication during vaso-occlusive crisis found one patient-related barrier (an increased number of hospital visits was associated with less optimal pain management) and one provider-related barrier (negative provider attitudes). ^145,^ ^146,^ ^155^ These studies also found one potential patient-related facilitator (dispositional optimism being associated with better patient use of pain medications) and two potential provider-related facilitators (provider female sex and fewer years in practice).

The six studies that addressed barriers to use of routine, scheduled care for sickle cell disease^147^–^152^ found one potential patient-related barrier (greater community socio-economic distress) and eight potential patient-related facilitators (greater parental knowledge, rural geographic region, higher self-efficacy, female patient sex, higher family problem-solving effort, higher family income, greater illness-related stress, and greater social support). Of note, the studies that found rural location to be a potential facilitator controlled for distance to the clinic, which may have eliminated the typical reason for decreased access by rural patients.

Results of descriptive studies of reported barriers. The results of studies employing descriptive methodologies to identify patient and provider-reported barriers to the use of therapies are summarized in Table 9.

Table 9 Summary of Barriers to the Treatment of Sickle Cell Disease Reported by Patients and Provider

| | Barriers (n studies identifying barrier)
Type of Treatment | Study Subjects (n studies) | Patient | Provider | Societal/System
Treatments to increase hemoglobin F | Providers (1) | Patient anticipation of side effects (1) | Concern about patient compliance (1) | Cost (1)
| | | Concern about side effects/carcinogenic potential (1)
| | | Doubts about effectiveness (1)
| | | Concerns about use in older patients (1)
| | | Concern about lack of patient contraception (1)
Established therapies for disease-management | Patients (2) | Forgetting medicine (2) | NR | NR
| | Disliking taste (1)
| | Concern about side effects (1)
| | Caregiver being busy (1)
| | Child falling asleep (1)
| | Running out of medicine (1)
Pain management during vaso-occulsive crisis | Patients (8) | Race (1) | Negative attitudes (13) | NR
| Providers (2) | | Lack of knowledge (5)
| Mixed (3) | | Lack of time (2)
| | | Inadequate pain assessment tools (2)
Receipt of routine scheduled care | NR | NR | NR | NR
Bone marrow transplantation | Providers (1) | Lack of donor (1) | Physician refusal (1) | NR
| | Lack of psychosocial or financial support (1)
| | Parental refusal (1)
| | History of noncompliance (1)
Non-specific ‘treatment’ or healthcare ‘quality’ | Providers (1) | Race (2) | Lack of knowledge (1) | NR
| Mixed (2) | Older age (1)
| | Male sex (1)

NR = not reported.

The one study that explored barriers to the use of treatments to increase Hb F (specifically, hydroxyurea) for patients with sickle cell disease found that providers reported the barriers to be patients' concerns about side effects and the providers' own concerns about the use of hydroxyurea in older patients, about patient compliance, about a lack of contraception, about side effects and carcinogenic potential, doubts about effectiveness, and concern about the costs to patients. ^93^

The two studies that addressed barriers to the use of established therapies for disease management both examined patient (caregiver)-reported reasons for missing doses of prophylactic antibiotic medication and found that caregivers reported missing doses as a result of forgetting, being too busy, running out of medication, having the child fall asleep, and the child not liking the taste of the medication. ^169,^ ^170^

All of the 13 studies that addressed barriers to the receipt of pain medications during vaso-occlusive crises found that both patients and providers reported that some type of negative provider attitude affected the quality of the pain management for patients with vaso-occlusive crisis. ^153^–^155,^ ^159^–^168^ Other barriers identified by patients and providers included poor provider knowledge of sickle cell disease (mentioned in five studies), lack of time (mentioned in two studies), inadequate pain assessment tools (mentioned in two studies), and race (mentioned in one study).

The one study that addressed barriers to bone marrow transplantation found that providers from bone marrow transplant centers reported that the major barriers to bone marrow transplantation for patients with sickle cell disease were lack of a donor, lack of psychosocial or financial support, a history of patient noncompliance, parental refusal, and physician refusal. ^158^

The three studies that addressed barriers to general healthcare quality found that patients and providers reported that three patient-related factors (patient race, older patient age, and patient male sex) may affect the quality of care provided to patients with sickle cell disease. ^156,^ ^157,^ ^171^

Strength of the evidence of the existence of barriers to the use of therapies in sickle cell disease. There was insufficient evidence to allow us to identify barriers to the use of hydroxyurea. Regarding barriers to the use of established therapies for sickle cell disease, four items were identified as either barriers, facilitators, or neither in more than two studies and thus were eligible for evidence grading. These were patient/family knowledge, number of hospital visits, patient age, and patient sex.

We concluded that the evidence that sex is not a barrier to the use of therapies was of a moderate grade. Largely due to the relative paucity of studies and their inconsistency, we concluded that there was only low-grade evidence that patient/family knowledge, the number of hospital visits, and patient age are barriers. The evidence for the remaining barriers to the use of established therapies was insufficient to allow us to draw any conclusions.

Regarding barriers to pain management, we identified two factors that were identified as a barrier in more than two studies and were thus eligible for evidence grading. These were negative provider attitudes and poor provider knowledge. Because of the quantity and consistency of these findings, we concluded that the evidence was high-grade that negative provider attitudes are barriers and moderate-grade that poor provider knowledge is a barrier to the use of pain medications for patients with sickle cell disease. The evidence for the remaining barriers to pain management was insufficient to allow us to draw any conclusions. There was insufficient evidence to allow us to identify barriers to the use of routine health services and bone marrow transplantation for sickle cell disease (Table 5).

### Characteristics of Studies Addressing Interventions to Overcome Barriers to the Appropriate Use of Therapies

Thirteen studies addressed interventions to increase the appropriate use of therapies. ^172^–^184^ None of these studies focused on interventions to increase the appropriate use of hydroxyurea. Nine focused on provider interventions to increase the appropriate provision of pain medications for patients with vaso-occlusive crisis, ^172^–^180^ three focused on patient interventions to improve adherence to therapies (desferoxime, ^181^ antibiotics, ^182^ and general adherence to health-promoting activities^183^), and one focused on a patient intervention to improve the receipt of routine, scheduled health care for sickle cell disease (Appendix C, Evidence Tables 27 and 28). ^184^

The majority of these interventions were assessed using observational (e.g., pre/post) study designs, but there were two RCTs^182,^ ^183^ and three studies that had a concurrent control group. ^173,^ ^175,^ ^176^ The majority of the studies were conducted in the United States, with two taking place in the United Kingdom^177^ ^179^ and one in Canada. ^182^

The majority of the provider interventions to improve pain management involved clinical protocols/pathways, ^172^–^175,^ ^178,^ ^180^ while one primarily involved audit and feedback, ^177^ and two involved changing the structure of care through the use of a day hospital^176^ or a fast-track admission process. ^179^ In addition, one of the clinical protocol/pathway interventions included staff sensitivity training. ^174^

The effect of interventions to improve pain management was measured directly in terms of its impact on pain management quality, as assessed by medical record review in six studies^173,^ ^175^–^177,^ ^179,^ ^180^ and patient ratings in three studies; ^174,^ ^179,^ ^180^ the effect of such interventions was also assessed indirectly through healthcare utilization in five studies^175^ ^172,^ ^174,^ ^176,^ ^178^ and healthcare costs in two studies. ^174,^ ^175^ No study examined the impact of an intervention directly on patient-reported levels of pain.

### Results of Studies Addressing Interventions to Overcome Barriers to the Appropriate Use of Therapies

A summary of the results of studies addressing interventions to increase the appropriate use of therapies is provided in Table 10 (see also Appendix C *, Evidence Tables 27 and 28).

Table 10 Results of Studies That Evaluated the Effect of a Patient or Provider Intervention to Improve Patient Adherence and Provider Provision of Appropriate Therapy for Patients with Sickle Cell Disease

| Patient interventions | Provider Interventions:
Type of Therapy | Outcome: Adherence to therapy | Outcome: Provision of appropriate therapy
Treatments to increase hemoglobin F | NR | NR
Established therapies for disease-management | Partial Improvement (1) | NR
| No Improvement (2)
Pain management during vaso-occulsive crisis | NR | Improvement (4)
| | Potential Improvement (5)
Bone marrow transplantation | NR | NR
Receipt of scheduled care | Improvement (1) | NR
Non-specific “treatment” or healthcare quality | NR | NR

NR = not reported.

Four of the studies that measured the impact of an intervention to improve the quality of pain management during vaso-occlusive crisis showed improvement in one or more direct outcomes, ^173,^ ^179,^ ^180,^ ^185^ while the remaining five studies showed potential improvement either through the suggestion of an improvement on a direct outcome (without a statistical test) or a statistically significant improvement in one or more indirect outcomes.

Two of the three studies that focused on patient interventions to improve adherence to therapies showed no effect of the intervention on patient adherence to desferoxime^181^ or to antibiotic prophylactic therapy. ^182^ One of the studies that focused on patient interventions to improve adherence to therapies showed no increase in health-promoting activities as a result of the intervention but did show some improvements in child health-related quality of life and child-parent relationships. ^183^

The one study that evaluated a patient intervention to improve receipt of routine, scheduled health care for sickle cell disease demonstrated a substantial and significant reduction in the percent of patients who had not attended clinic over the past 2 years. ^184^

The strength of the evidence addressing interventions to overcome barriers to the use of therapies. The evidence was insufficient to allow us to identify interventions to overcome barriers to the use of hydroxyurea and bone marrow transplantation.

None of the three studies testing interventions to improve patient adherence to established therapies for chronic disease management showed any effect on patient adherence. However, due to the small sample sizes and diverse outcome measures, we concluded that there was only low-grade evidence that interventions cannot improve patient adherence.

We concluded that there was moderate evidence that interventions can overcome barriers to the use of pain medications and moderate evidence to support the contention that interventions can overcome barriers to the receipt of routine, scheduled healthcare for patients with sickle cell disease (Table 5).