# Appendix F: Technical Experts and Peer Reviewers

- Kofi Anie, PhD
- Clinical Health Psychologist
- Central Middlesex Hospital
- Honorary Senior Lecturer
- Imperial College London
- London, England

- Wylie Burke, MD, PhD
- Professor and Chair
- Department of Medical History and Ethics
- University of Washington
- Seattle, WA

- Christine Corbin
- Program Coordinator
- Sickle Cell Disease Association of America, Inc
- Baltimore, MD

- Peter Fagan, PhD
- Johns Hopkins HealthCare LLC
- Glen Burnie, MD

- Jeffery Keefer, MD, PhD
- Division of Pediatric Hematology
- Johns Hopkins University School of Medicine
- Baltimore, MD

- Erica Liebelt, MD, PhD
- National Toxicology Program
- Associate Professor of Pediatrics and Emergency Medicine
- Director, Medical Toxicology Services
- UAB School of Medicine
- Birmingham, AL

- Heidi Malm, PhD
- Associate Professor
- Loyola University Chicago
- Chicago, IL

- Martin H. Steinberg, MD
- Professor of Medicine, Pediatrics, Pathology and Laboratory Medicine, Boston University School of Medicine
- Director,
- Center of Excellence in Sickle Cell Disease
- Boston Medical Center
- Boston, MA

## Internal Technical Experts

- Samuel Charache, MD, PhD
- Emeritus Professor of Medicine and Pathology
- John Hopkins School of Medicine
- Baltimore, MD

- James F. Casella, MD
- Rainey Professor of Pediatric Hematology
- Department of Pediatrics
- Johns Hopkins University
- School of Medicine
- Baltimore, MD

- Cynthia S. Rand, PhD
- Professor of Medicine
- Division of Pulmonary and Critical Care Medicine
- Johns Hopkins University
- School of Medicine
- Baltimore, MD