# Appendix E: Evidence Grading

Score Sheet -Efficacy in Children with SCD

| | Outcomes
| | Hb F% change | Reduction in crises (pain/ACS) | Reduction in hospitalization | Reduction in neurological events | Reduction in transfusion
1 | Protection against risk of bias (relates to study design, study quality, reporting bias)
2 | Did the studies have important inconsistency? (-1)
3 | Was there some (-1) or major (-2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest?
4 | Were the studies sparse or imprecise? (-1)
5 | Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2))
6 | Did the studies have evidence of a dose-response gradient? (+1)
7 | Did the studies have unmeasured plausible confounders that affected the magnitude of the observed association? (+1)
| Overall grade of evidence (high, moderate, low, very low) (insufficient if no studies or evidence is too sparse or inconsistent to draw conclusions)

* enter 0 if the studies evidence does not warrant a (-) or (+) score

Score Sheet -Efficacy in Adults with SCD

| | Outcomes
| | Hb F% change | Reduction in crises (pain/ACS) | Reduction in hospitalization | Reduction in neurological events | Reduction in transfusion | Mortality
1 | Protection against risk of bias
2 | Did the studies have important inconsistency? (-1)
3 | Was there some (-1) or major (-2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest?
4 | Were the studies sparse or imprecise? (-1)
5 | Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2))
6 | Did the studies have evidence of a dose-response gradient? (+1)
7 | Did the studies have unmeasured plausible confounders that affected the magnitude of the observed association? (+1)
| Overall grade of evidence (high, moderate, low, very low) (insufficient if no studies or evidence is too sparse or inconsistent to draw conclusions)

Score Sheet -Toxicity in Children with SCD

| | Outcomes
| | Leukemia (MDS/AML/Cytogenetic abnromalities | Developmental toxicities (in utero) | Leg ulcers | Growth delays | Developmental toxicities in next generation
1 | Protection against risk of bias (relates to study design, study quality, reporting bias)
2 | Did the studies have important inconsistency? (-1)
3 | Was there some (-1) or major (-2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest?
4 | Were the studies sparse or imprecise? (-1)
5 | Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2))
6 | Did the studies have evidence of a dose-response gradient? (+1)
7 | Did the studies have unmeasured plausible confounders that affected the magnitude of the observed association? (+1)
| Overall grade of evidence (high, moderate, low, very low) (insufficient if no studies or evidence is too sparse or inconsistent to draw conclusions)

Score Sheet -Toxicity in Adults with SCD

| | Outcomes
| | Leukemia (MDS/AML/Cytogenetic abnromalities | Leg ulcers | Skin neoplasms | Secondary malignancies | Adverse preg. Outcomes | Spermatogenesis defects
1 | Protection against risk of bias (relates to study design, study quality, reporting bias)
2 | Did the studies have important inconsistency? (-1)
3 | Was there some (-1) or major (-2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest?
4 | Were the studies sparse or imprecise? (-1)
5 | Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2))
6 | Did the studies have evidence of a dose-response gradient? (+1)
7 | Did the studies have unmeasured plausible confounders that affected the magnitude of the observed association? (+1)
| Overall grade of evidence (high, moderate, low, very low) (insufficient if no studies or evidence is too sparse or inconsistent to draw conclusions)

Score Sheet -Toxicity in Adults with Other Diseases

| | Outcomes
| | Leukemia (MDS/AML/Cytogenetic abnormalities | Leg ulcers | Skin neoplasms | Secondary malignancies | Adverse preg. Outcomes | Spermatogenesis defects
1 | Protection against risk of bias (relates to study design, study quality, reporting bias)
2 | Did the studies have important inconsistency? (-1)
3 | Was there some (-1) or major (-2) uncertainty about the directness or extent to which the people, interventions and outcomes are similar to those of interest?
4 | Was the data sparse or imprecise (-1)
5 | Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2))
6 | Did the studies have evidence of a dose-response gradient? (+1)
7 | Did the studies have unmeasured plausible confounders that affected the magnitude of the observed association? (+1)
| Overall grade of evidence (high, moderate, low, very low) (insufficient if no studies or evidence is too sparse or inconsistent to draw conclusions)

[underlined: Grading the Evidence for Key Question 4 - Barriers to Therapies]

Grading the Evidence for the Cross-sectional and Descriptive Studies about the Presence of Barriers

After all of the articles were reviewed, the body of the evidence supporting the existence of particular barriers for each question was graded on the basis of the number of times the barrier was identified (quantity), protection against the bias in the studies (quality), and consistency.

First, the quantity of the evidence was initially judged as being Strong, Moderate, or Low on the basis of the following criteria: there had to be more than ten studies identifying a particular factor (i.e. potential barrier or facilitator) to meet criteria for a “High” grade, six to ten studies to meet criteria for a “Moderate” grade, three to five studies to meet the criteria for a “Poor” grade, and two or fewer studies to meet the criteria for an “Insufficient” grade.

The initial grade for the evidence was then lowered by one level (i.e., changing from High to Moderate or from Moderate to Low) if 75% or less of the studies reviewed for each question attempted to protect against the risk of bias through controlling for potential confounders in the cross-sectional studies OR if the reported barriers were not cited by the population that would be most knowledgeable about the barrier in the descriptive studies (e.g. healthcare providers themselves saying they had limited knowledge was considered greater protection against bias than if patients had reported the same finding). The initial quantity score was left unchanged if our criteria for protection against the risk of bias were met.

The resulting score was then revised further based on the consistency of the evidence, which was an assessment of the extent to which any particular factor (i.e. potential barrier or facilitator) was found across studies to be a barrier to, a facilitator of, or to have no association with the appropriate therapy of interest. The score was lowered by one level if less than 75%, and lowered by two levels if less than 50%, of the studies found an independent variable to be a barrier, facilitator, or have no association with the therapy of interest. The score was raised by one level (i.e., from Poor to Moderate or from Moderate to High) if 100% of the studies examining any particular independent variable found it to be a barrier, facilitator, or have no association with the therapy of interest.

Grading the Evidence for the Intervention Studies

Criteria to grade the body of the evidence for the intervention studies were similar to the criteria used earlier in the report, and therefore were different criteria than that presented above for KQ4a-e. For each therapy of interest, the evidence that an intervention could overcome barriers to that therapy of interest was given an initial grade of High if the evidence contained at least one randomized controlled trial, Moderate if there was at least one controlled trial (not randomized), and Low if the evidence contained no controlled trials. Grades of High or Moderate were then lowered by one level if there were serious concerns about the presence of bias in the findings.

Grades were lowered by one additional level in the presence of important inconsistencies in the findings across studies, any uncertainty about the directness or extent to which the people, interventions, and outcomes were similar to the sickle cell populations of interest, or if the findings were too imprecise or sparse to estimate an effect.

Grades were then raised by one additional level in the presence of strong evidence of association between the intervention and the outcome, evidence of a dose-response gradient, or if all plausible unmeasured confounders would have reduced the observed effect. Grades were raised by two levels in the presence of very strong evidence of association between the intervention and the outcome.

The overall grade of the body of this evidence was given as the final grade that resulted from the above assessments. A grade of Insufficient was given if there were no studies examining potential interventions to overcome barriers to an appropriate therapy of interest, or of the existing body of evidence was deemed to be too sparse or inconsistent to draw conclusions.