# Appendix C: Evidence Tables

Evidence Table 1. Description of Randomized Controlled Trials Investigating the Efficacy of Hydroxyurea Treatment for Sickle Cell Disease

Author, year | Location | Design | Recruitment start date - end date | Inclusion and exclusion criteria | Intervention | Starting dose: titration dose | Planned duration of treatment | Jadad ^29^ score
Adults-MSH
Charache, 1995^21^ | North America | RCT | Jan 1992 – Apr 1993 | Inclusion: Age >18; SCA; Hb Sα^+^ thal, Pain >3/yr | | | 2 years | 5
Charache, 1996^39^ | | | | Exclusion: Hb Sβ^+^ thal; β^0^ thal; SC; xfuse dependant; Preg; Op; SA; CTA; stroke in last 6 years; HIV; HU; not willing to use contraception; blood counts that could not be distinguished from marrow suppression; >15% HbA if recent transfusion; breastfeeding | | | 2 years | 4
Hackney, 1997^41^ | | | | | | | 18 months | 3
Steinberg, 1997^40^ | | | | | | | 2 years | 4
Moore, 2000 ^22^ | | | | | | | 2 years | 4*
Steinberg, 2003^43^ | | Cohort (f/u of MSH) | | | | | | ^†^
Ballas, 2006^42^ | | RCT | | | HU | 15 mg/kg/day: increased 5 mg/kg every 12 weeks if ANC ≥2000, retic and platelets ≥80,000/ul, and Hb ≥4.5 g/dl | 2 years | 4
| | | | | Placebo | Escalation per Data Coordinating Center (random)
Pediatric-Belgian Trial
Ferster, 1998^44^ | Europe | Cross-over | June 1992 – Dec 1993 | Inclusion: SCA, Hb Sα^+^ thal; 3/yr pain episodes, stroke; acute chest; splenic sequestration | HU | 20mg/kg/day: increased by 5mg/kg/day after 2 months, if no response increased to 25 mg/kg | 6 months | 3
| | | | Exclusion: Hb Sβ^+^ thal; Hb S β^0^ thal | Placebo | Not described | 6 months

* Quality Deficiency: No description of withdrawals or dropouts.

† Observational Study

+ ANC = absolute neutrophil count; CTA = concurrent treatment with an anti-sickling agent; f/u = follow up; Hb Sβ thal = sickle β thalassemia; Hb S β^0^ thal = Sickle β^0^ thalassemia; Hb Sα thal = Sickle α thalassemia; HbA = hemoglobin A; HIV = Human Immunodeficiency Virus; HU = hydroxyurea; MSH = Multicenter Study of Hydroxyurea for Sickle Cell Anemia; Op = opioid use; Pain = pain episode; Preg = pregnancy; RCT = Randomized controlled trial; retic = reticulocytes; SA = substance abuse; SC = SC genotype; SCA = sickle cell anemia; xfuse = transfusion dependant.

Evidence Table 2. Adequacy of Reporting in Sickle Cell Disease Controlled Trials

Author, year | Source population | Inclusion criteria | Baseline characteristics | Intervention | Adherence | Q Score
Ballas, 2006 ^42^ | 1 | 1 | 1 | | 1 | 4
Moore, 2000 ^22^ | 1 | 1 | 1 | 1 | 0 | 4
Hackney, 1997 ^41^ | 1 | 1 | 1 | | 0 | 3
Steinberg, 1997 ^40^ | 1 | 1 | 1 | | 1 | 4
Charache, 1996 ^39^ | 1 | 1 | 1 | | 1 | 4
Charache, 1995 ^21^ | 1 | 1 | 1 | 1 | 1 | 5
Ferster, 1998 ^44^ | 1 | 1 | 0 | | 1 | 3

* Blank cells represent categories that were not applicable to the question.

Q = quality

Evidence Table 3. Description of Patient Populations in Randomized Controlled Trials Concerning the Efficacy of Hydroxyurea in Sickle Cell Disease

Author, year | Patient groups | N | Recruitment start date - end date | Mean Age | % Male | Race, n | Genotype/ haplotype, n (%) | Last observation
| Intervention
MSH
Charache, 1995 ^21^ | HU | 152 | Jan 1992–April 1993 | 30 | 49 | Black Non-Hispanic, 149 Black Hispanic, 1 Other, 2 | SS, 151; Hb Sβ^0^ thal, 1 Benin/Benin, (36); Benin/CAR, (21); Benin/Senegal, (3); Senegal/CAR, (3), Other (23) | 28 months
| Placebo | 147 | | 31 | 48 | Black Non-Hispanic, 142; White Hispanic, 2 Other, 3 | SS, 145; Hb Sβ^0^ thalassemia, 2, Benin/Benin, (43); Benin/CAR, (20); Benin/Senegal, (3); Senegal/CAR, (3), Other (17)
Charache, 1996 ^39^ | HU | 152 | Jan 1992–April 1993 | 30 | 49 | Black Non-Hispanic, 149 Black Hispanic, 1 Other, 2 | SS, 151; Hb Sβ^0^ thal, 1 Benin/Benin, (36); Benin/CAR, (21); Benin/Senegal, (3); Senegal/CAR, (3), Other (23) | Mean 28±6 months
| Placebo | 147 | | 31 | 48 | Black Non-Hispanic,142 White Hispanic, 2 Other, 3 | SS, 145; Hb Sβ^0^ thal, 2, Benin/Benin, (43); Benin/CAR, (20); Benin/Senegal, (3); Senegal/CAR, (3), Other (17) | Mean 28±7 months
Hackney, 1997 ^41^ | HU | 10 | Jan 1992–April 1993 | 30.5 | 60 | | SS (100) | 18 Months
| Placebo | 14 | | 29.8 | 57
Steinberg, 1997 ^40^ | HU | 152 | Jan 1992–April 1993 | 30 | | | | Mean 28 months (range = 21–38)
| Placebo | 147 | | 31
Moore, 2000 ^22^ | HU | 152 | Jan 1992–April 1993 | 30 | 49 | | | NR
| Placebo | 147 | | 31 | 48
Steinberg, 2003 ^43^ | HU | 152 | Jan 1992–April 1993 | | | | | 7.7 years
| Placebo | 147 | | | | | | 7.4 years
Ballas, 2006 ^42^ | HU | 141 | Jan 1992–April 1993 | | | | SS (100) | 24 months
| Placebo | 136
Other trial
Ferster, 1998^44^ | HU | 25 | June 1993–Dec 1993 | Median, 9; Range, 2–22 | 48 | Black Non-Hispanic, 25 | SS, 25 | 12 months

0 CAR = Central African Republic; Hb = hemoglobin; Hb Sβ thal = Sickle β thalassemia; HU = hydroxyurea; NR = not reported; SS = Sickle Hemoglobin SS Disease.

Evidence Table 4. Design of Observational or Single-Arm Studies of Hydroxyurea in Sickle Cell Disease

Author | Location | Patient type/design | Study Goal | Objective | Recruitment start date - end date | Inclusion and exclusion criteria | HU Starting Dose: Titration schedule | Mean Observation Duration in months, (SD) [range] | Q score
HUG-KID CLUSTER
Kinney, 1999^68^ | North America | Children-prospective | Toxicity | To determine the safety and efficacy of HU in pediatric patients with SCA. This is the phase I/II HUG KIDS study- goal was to establish MTD | Dec 1994–Mar 1996 | Inclusion: 5–15 years, SCA, pain ≥ 3/yr or ACS episodes in last year, 6 documented heights and weights for at 2 years preceding enrollment | 15mg/kg/d: Up 5mg/kg for 8 wks up to 30mg/kg | Up to 24 | 86
| | | | | | Exclusion: Trans, preg, renal failure, liver failure, sepsis, ALT > 2, HIV+, theophyline containing drugs, estrogen, Ca-blockers
Ware, 2002^73^ | North America | Children-prospective | Efficacy* | To identify predictors of Hb response in school-aged children with SCA receiving HU at MTD | Dec 1994–Mar 1996 | Inclusion: Age = children, Pain ≥3 in past year or ≥ 3 pain and ACS episodes within 1 year of enrollment, ACS ≥3 in past 2 years | 15 mg/kg/d: Increase every 8 weeks to MTD or 30mg/kg | 11.7 | 86
| | | | | | Exclusion: renal failure, “dysfunction”, liver failure
Zimmerman, 2004^81^ | North America | Children-prospective | Effectiveness | To investigate the long-term efficacy of HU (in improving hematologic parameters) in children with SCD receiving the MTD^†^ | 1995-2002 | Inclusion: on HU for at least 6 mo, SCD | 15 or 20mg/kg: Up to 30mg/kg if tolerated | 45 (24) [6–10] | 88
HUSOFT Cluster
Wang, 2001^60^ | North America | Children-prospective | Efficacy | To conduct a collaborative pilot trial of HU in infants with SCA to assess (1) feasibility of administration, (2) toxicity, (3) hematologic effects, and (4) effect on spleen function^‡^ | Nov 1996 – Jun 1997 | Inclusion: Age, infants-not specified by age, SCA, Hb Sβ^0^ thal | 20mg/kg: No titration | 24 | 67
| | | | | | Exclusion: Splenomegaly, Preg, renal failure, CRCL<120ml/min/1.73 m2, liver failure, ALT>5n, HIV+, iron deficiency, HbA>10% from transfusion, sig. non-sickle-related medical problem
Hankins, 2005^72^ | North America | Children-prospective | Efficacy | To study the long-term efficacy and toxicity of HU on infants, and to define the role of HU in preventing organ dysfunction | as in HUSOFT | Inclusion: enrolled in HUSOFT^§^ | 20mg/kg: 5mg/kg every 6 months to max 30mg/kg | 58.8 [25–72] | 67
French Cluster
de Montalembert, 1997^76^ | Europe | Children-prospective | Efficacy | To observe the safety and efficacy of HU in previously severely ill children with SCD | NR | Inclusion: Age, 4 to20 years, SCA, Hb Sβ^+^ thal, Hb Sβ^0^ thal, S α^+^ thal, SC, Pain ≥ 3 hospitalizations in last year | 20 mg/kg/day 4 days/week: Increase 5 mg/kg/day every 4 weeks to a max dose of 40 mg/kg/day | 32 [12 to 59] | 85
| | | | | | Exclusion: HIV+, renal insufficiency CrCL <120ml/1.73 mˆ2/min, iron deficiency or current iron supplementation, history of frequent and severe infections, monthly f/u would be difficult, hypersplenism, hepatic insufficiency (ALT>5×ULN, or chronic hepatic disease)
Maier-Redelsperger, 1998^75^ | Europe | Children-prospective | Efficacy | To study the cellular and molecular responses to long-term HU treatment in 29 severely affected young patients with SCD | NR | Inclusion: Pain | 20mg/kg/d 4 d/wk: Increase 5mg/kg/d monthly to max 40^‖^ | 22 [12 to 36] | 77
| | | | | | Exclusion: Preg, renal failure, renal function within normal limits, liver failure, ALT >1.5 ULN, HIV+, hx of severe infections, iron deficiency
de Montalembert, 1999 ^55^ | Europe | Children-prospective | Toxicity | To evaluate the tolerance of HU in children affected with SCD | NR - Sep 1998 | Inclusion: 2–20 years when starting HU | NR | 22 [0.5–93] | 18
de Montalembert, 2006 ^48^ | Europe | Children-prospective | Toxicity | To asses the tolerability of HU treatment in 225 children with SCD | Jan 1992 – Dec 2003 | Inclusion: Pain ≥ 3 admissions, stroke and unable or refused transfusion, ACS, recurrent severe chronic anemia Hb < 6–7, high TCD velocity, cardiac ischemia | 20 mg/kg/d 4 d/wk, then 4 to 7 d/wk from 1997-2003: Up to 40 mg/kg/d, increased up to 40 mg/kg/d if no response after 6 months | 46 [0–152] | 71
Belgian Cluster
Ferster, 2001^58^ | Europe | Children-prospective | Effectiveness | To evaluate the long-term efficacy and toxicity of HU in the Belgian registry of HU-treated SCD patients | 1993 - NR | Inclusion: Age, children and young adults, Pain ≥ 2 admissions/year, or stroke, or TIA, or ACS, or priapism, ischemic bone | 20mg/kg: 5mg/kg at will of doctor^¶^ | 42 | 63
Gulbis, 2005^82^ | Europe | Children-prospective | Effectiveness | To assess the efficacy and safety of HU | 1993-2002 | Inclusion: Age, children and young adults, Pain ≥ 2 admissions/year, or stroke, or TIA, or ACS, or priapism, or ischemic bone | 20mg/kg: 5mg/kg at will of doctor | 47^#^ | 54
Others
el-Hazmi, 1992^45^ | Middle East | Adults-prospective | Efficacy | To assess the effectiveness of HU in managing severe forms of SCD | | NR | 20mg/kg/day: no titration | 3 | 57
Charache. 1992^46^ | North America | Adults-prospective | Efficacy | To assess pharmacokinetics, toxicity, and increase in fetal Hb production in response to daily doses of HU in patients with SCA | Feb 1988-NR | Inclusion: Age >18 years, SCA, S α^+^ thal, pain admissions >1 in last year (including ED visits) | 10 – 20 mg/kg/d depending on AUC at 6 hours: Increase 5 mg/kg/d Every 8 weeks | 9 [0–25] | 89
| | | | | | Exclusion: Hb Sβ^+^ thal, Hb Sβ^0^ thal, Trans, preg, renal failure, abnormal renal function tests, liver failure, abnormal hepatic function tests, HIV+, AST >100 U/L, albumin <3 g/dl, theophylline containing drugs, androgens, estrogens, or progesterones (other than birth control)
Voskaridou, 1995^78^ | Europe | Adults-prospective | Efficacy | To report on the response of Caucasian patients with SCD with complications of the disease (pain crises) to high “sub-toxic” doses of HU | NR | Inclusion:, Hb Sβ^+^ thal, Hb Sβ^0^ thal, pain frequent | 15 mg/kg/d, rounded up to the next 500mg 4days/wk: Increase by 5mg/kg increments, rounded up to the next 500mg q 4wks, maximal total dose of 2.5g/d** | [5–8.7] | 54
Scott, 1996^77^ | North America | Children-prospective | Efficacy | To assess the safety and efficacy of HU for the treatment of severe SCD in children | Feb 1992 – Jun 1995 | Inclusion: Age 10 to 17 years, SCA, Hb Sβ^0^ thal, S α^+^ thal, pain admissions ≥ 3/year, ACS, or priapism, contraceptive measures to prevent pregnancy | 10–20 mg/kg/day: 5 mg/kg/day Every 12 weeks | 43.6 [24–63] | 93
| | | | | | Exclusion: abnormal renal or hepatic function, noncompliance
Loukopoulos, 1998^69^ | Europe | Adults-retrospective | Efficacy | To report on the effectiveness of HU in patients with thalassemia—a report of a physician's experiences | NR | Inclusion: Age, adults, Hb Sβ^+^ thal, Hb Sβ^0^ thal | 15–35 mg/kg/day on 4–7 days/week: no titration | NR | 23
Olivieri, 1998^64^ | North America | Children-prospective | Toxicity | To monitor compliance with treatment of HU and evaluate the impact of HU on splenic function in children with SCD | NR | Inclusion: SCA, Pain ≥ 3 in the previous yr, ACS, any episode in the previous yr | 12.9 ± 2.7 mg/kg/d, reduced to 10mg/kg/d later: Dose increased by 5 mg/kg q 8–12 wks until ANC<2,000/ml, retic < 80,000/ml, plt<100k/mcL, or Hb more than 2g/dL below steady state | 18 | 88
| | | | | | Exclusion: Neutropenia, Trans, Preg, SA or severe psychologic disease interfering with accurate reporting of pain, renal failure, liver failure, ALT >x2UNL, untreated folate or iron deficiency, thrombocytopenic conditions
Hanft, 2000^57^ | North America | Adults and Children-retrospective | Toxicity | To investigate the mutagenic and carcinogenic potential of long-term HU use in patients with SCD or MPDs | NR | Inclusion: SCA, MPD, abnormal TCD, cardiac ischemia | NR | up to 180 | 31
Loukopoulos, 2000^74^ | Europe | Adults-prospective | Efficacy | To report on a clinical trial of HU in 55 Greek-origin patients with sickle cell/B thalassemia and patients with homozygous HbS disease who had been treated with HU for several years | NR-Jun 1999 | Inclusion: Age ≥ 17 years, SCA, Hb Sβ^+^ thal, Hb Sβ^0^ thal, pain ≥ 3/yr, severe disease (e.g. stroke, hyperbiliuremia) | 15mg/kg/day for 4 days week then 25 mg/kg/day: Titrate up to 25mg/kg/d stable for 6mos and taper to 1.0g daily | [6–48] | 63
| | | | | | Exclusion: pregnancy or intention to conceive
Rigano, 2001^71^ | Europe | Adults-prospective | Efficacy | To evaluate the efficacy of HU in a group of 22 Sicilian patients with BS/B-thal by studying the incidence of crises, frequency of hospitalization, complications and mortality | NR | Inclusion: Sicilians, ≥ 3 sickle crises (any type) in previous year | 15 mg/kg/day: Increased after 3 months if no response | >24 | 70
| | | | | | Exclusion: HIV^+^, bone marrow hypoplasia
Chaine, 2001^66^ | Europe | Adult-retrospective | Toxicity | To evaluate the risk of cutaneous adverse reactions in SCD patients treated with HU | NR | Inclusion: adult, SCA, Hb Sβ^+^ thal, Hb Sβ^0^ thal, S α^+^ thal, SC, on HU^††^ | NR | 12 (MTD plus time to escalate) | 52
Al-Jam'a, 2002^70^ | Middle East | Adults-Children-prospective | Efficacy | To assess the efficiency and safety of HU in patients with SCD from the Eastern Province, Kingdom of Saudi Arabia | Jun 1994 – Jun 1998 | Inclusion: Age, >5 years, SCA, Hb Sβ^+^ thal, Hb Sβ^0^ thal, S α^+^ thal, pain ≥ 4 admissions for VOC in past year | 500 mg/day, 500 mg QOD if wt <50 kg: 500 mg each month until MTD or 35 mg/kg reached | 18.5 [12 to 49] | 89
| | | | | | Exclusion: Trans, Preg, renal failure, abnormal renal tests, liver failure, abnormal hepatic function tests, HIV+, progesterones other than in OCPs, theophyllines, androgens, estrogens
Ferguson, 2002^52^ | North America | Adults-retrospective^‡‡^ | Effectiveness | To assess the efficacy of HU in settings outside a clinical trial with longer follow-up | Sep 1997 – Sep 1999 | Inclusion: Age, adults, SCA, treated at two hospitals | Every 8 weeks | 21.6 [3–60]^§§^ | 57
| | | | | | Exclusion: Hb Sβ^+^ thal, Hb Sβ^0^ thal, Sα^+^ thal, SC, Trans, Preg, SA, stroke in past 6 years
Schultz, 2003^53^ | North America | Adult-retrospective | Toxicity | To report on cases of malignancy in patients with SCD | | | NR | 22 | 14
Cummins, 2003^61^ | Europe | Adults-prospective ^‖‖^ | Efficacy | To compare patients with SCD treated with cognitive behavioral therapy with patients treated with HU in terms of quality of life, pain experience, health service utilization, and pain coping strategies | Jan 2000–Dec 2002 | Inclusion: Age, adult, SCA, Hb Sβ^+^ thal, Hb Sβ^0^ thal, S α^+^ thal, SC | Weight-based | 23 [12–39] | 37
Ware, 2004^67^ | North America | Children-prospective | Effectiveness | To describe the clinical outcome and long-term follow-up for a cohort of pediatric patients with SCD receiving HU for prevention of secondary stroke | NR | Inclusion: Age = pediatric, SCA, Trans, stroke | 15–20 mg/kg per day | 29 [12–49] | 88
| | | | | | Exclusion: Hb Sβ^+^ thal, S α^+^ thal, S α^+^ thal, SC
Bakanay, 2005^51^ | North America | Children-Retrospective | Effectiveness | To report on the demographic, clinical and laboratory characteristics of a group of patients who died of complications while on HU therapy compared with HU-treated surviving patients | NR | NR | 15 mg/kg/day: 5mg/kg as tolerated | 36 [5–78] | 50
Vicari, 2005i^80^ | Central or South America or Mexico | Adults-prospective | Effectiveness | To see if genetic determinants influence response and toxicity with HU | NR | Inclusion: Age, >18 years, SCA, Pain ≥3/yr, ACS | NR | 30.45 [12–60] | 25
| | | | | | Exclusion: HIV+, bone marrow depression
Khayat, 2006^47^ | Central or South America or Mexico | Adults and children-retrospective | Toxicity | To determine the frequency of chromosome aberrations and the mitotic index as a criteria for evaluation of the genotoxicity and cytotoxicity of HU in SCD patients | NR | NR | 25mg/kg/d | 12 | 27
Kratovil, 2006^62^ | North America | Children-prospective | Efficacy | To determine if HU therapy affected transcranial Doppler velocities and whether changes in velocities could be associated with changes in hematologic parameters | 1998-2004 | Inclusion: SCA, Pain >5/year, stroke and not transfused, 2nd alloantibodies, or poor chelation, severe ACS, TCD exam before and during HU | 15 mg/kg/day: 5 mg/kg/day every 8 weeks to max of 30–25 mg/kg/day or 2000 mg/day or MTD | [6–48] | 73
| | | | | | Exclusion: Trans, none in 6 months, SA, drugs
Ataga, 2006^79^ | North America | Adults-prospective | Effectiveness | To evaluate the trends of development of pulmonary hypertension, the association of pulmonary hypertension with clinical and laboratory measures and the effect of pulmonary hypertension on mortality in SCD patients | NR | Inclusion: SCA, Hb Sβ^+^ thal, Hb Sβ^0^ thal, S α^+^ thal, SC | NR | NR | 40
| | | | | | Exclusion: ACS in last 4 weeks, current crisis or acute illness
Svarch, 2006^50^ | Central or South America or Mexico | Children-retrospective | Efficacy | To demonstrate that good results can be achieved and toxicity avoided by maintaining dose of HU at 15 mg/kg/day in patients with SCD | NR | Inclusion: Age, 4–18 years, SCA, Pain ≥ 3 in past year or, sepsis ≥ 1 in past 2 years | 15mg/kg/d: No titration | Median = 24 | 35
| | | | | | Exclusion: ACS
Zimmerman, 2007^63^ | North America | Children-prospective | Efficacy | To describe a prospective, single-institution Phase II trial of HU for children with SCD and increased transcranial doppler flow velocities | 2000-2004 | Inclusion: Age all pediatric, SCA, S/O Arab | “as in routine practice”: To MTD | 10 (5) | 73
| | | | | | Exclusion: sickle β^+^ thal, sickle β^0^ thal, sickle α^+^ thal, SC | | Median = 8
McKie, 2007^49^ | North America | Children-retro spective | Effectiveness | To define the age of onset of microalbuminuria and proteinuria in children with SCD and evaluate their association with age, sex, and hemoglobin levels, Also to explore the safety and utility of HU and ACEI in prevention and treatment of sickle cell nephropathy | Sep 1996–Dec 2002 | Inclusion: Age, >2 and < 21 years, SCA | 15 mg/kg/day: Based on clinical responses, MCV, HbF | 21.8 | 50
Harrod, 2007^56^ | North America | Children-prospective | Toxicity | To quantitate Howell-Jolly Bodies in a large cohort of children with SCD and analyze according to sicklegenotype, age, splenectomy status, and HU exposure | NR | Inclusion: < 20 years | NR | NR | 39
| | | | | | Exclusion: Hb Sβ^+^ thal, Hb Sβ^0^ thal
Hankins, 2007^65^ | North America | Children-prospective | Effectiveness | To investigate the effects of HU on spleen and brain through retrospective data review of children with SCD treated with HU | Jul 1995 – Oct 2004 | Inclusion: children, SCA, Hb Sβ^0^ thal | 15–20 mg/kg/day: Every 8weeks to 30–35mg/kg^¶¶^ | 29 [2–103] | 43
Santos, 2002 ^59^ | Central, South America | Children-prospective | Effectiveness | To evaluate the effects of long-term therapy with hydroxyurea on recovery of splenic function | NR | Inclusion: Age 3 to 22, SCA, Sβ0 thal, ≥ 2 episodes of priapism or ACS, ≥ 6 painful crisis | 15 mg/kg/day: every 8 weeks increase by 5 mg/kg/day to max of 30 mg/kg/day or toxicity | 12 months | 47

* Used data from the phase I/II HUG KIDS study but analyses only included children who reached MTD; 5.6% of pills were returned.

† Included patients who were in HUG-KIDS (n=15), in HUSOFT (n=7), and 33 patients in a secondary prevention of stroke study.

‡ Investigators matched 3 patients from CSSCD to enrolled patients by diagnosis, gender, age.

§ This was the extension study of HUSOFT. Of the 21 who completed the 2 years in HUSOFT, 17 (of the 21) completed 4 years, and 11 (of the 21) completed 6 years from start.

‖ Mean dosage 34.2mg/kg administered 4 days a week.

¶ At the end of year one of the study, 55% were on 20–25mg/kh, 41% were under 20mg/kg, 4% were on 25–30mg/kg, and 1 was on more than 30mg/kg.

# 109 patients for a total of 426 patient-yrs. The initial 109 children were followed for up to 8 years (14 children with this duration).

** The maintenance phase (after first 24 weeks) was 100mg/d for 4d/week and then patients were put into one of three arms that differed slightly in administration.

†† Recruited all adult patients who came to their institution for skin exam who had SCD and were on HU.

‡‡ Patients were stratified by duration of therapy (or completeness of therapy). Fourteen patients had previously participated in MSH study.

§§ Mean observation duration was 9.7 months in the group on HU for <24 months.

‖‖ The cross-sectional design was based on questionnaires (in 2002 for HU patients, 2000 for CBT patients) and review of records: there is a strong likelihood of selection bias.

¶¶ The median MTD was 30mg/kg/day (range 15–35 mg/kg/day).

+ ACEI =ACE Inhibitors; ACS = acute chest syndrome; ALT = Alanine Aminotransferase; ANC = absolute neutrophil count; AUC = area under the curve; BS/B-thal = hemoglobin S beta-thalassemia; Ca = calcium; CBT = cognitive behavioral therapy; CrCL = creatinine clearance; CSSCD = Cooperative Study of Sickle Cell Disease; ED = Emergency Department; f/u = follow up; Hb = hemoglobin; Hb Sβ thal = Sickle β thalassemia; Hb S β^0^ thal = Sickle β^0^ thalassemia; HbA = hemoglobin A; HbF = fetal hemoglobin; HbS = sickle hemoglobin; HU = hydroxyurea; HUG KIDS = pediatric hydroxyurea safety trial; HUSOFT = The Hydroxyurea Safety and Organ Toxicity trial; hx = history; MCV = mean corpuscular volume; MPD = myeloproliferative disorder; MSH = Multicenter Study of Hydroxyurea for Sickle Cell Anemia; MTD = maximum tolerated dose; NR = not reported; OCP = oral contraceptive pill; plt = platelets; Preg = pregnancy; Q = quality; QOD = 4 times a day; retic = reticulocytes; S α thal = sickle α-thalassemia; S/O = hemoglobin SO Arab; SA = substance abuse; SC = Sickle-Hemoglobin C Disease; SCA = sickle cell anemia; SCD = Sickle Cell Disease; SD = standard deviation; TCD = transcranial Doppler; TIA = transient ischemic attack; Trans = transfusion; ULN = upper limit of normal; VOC = vaso-occlusive crisis.

Evidence Table 5. Adequacy of Reporting in Observational Studies and Surveys on Hydroxyurea Use in Sickle Cell Disease*

Observational Studies
Author, year | Study description | Inclusion or exclusion criteria described | Key characteristics of participants described | Intervention described | Adherence to the drug described | Adjusted or stratified estimate of the treatment effect provided | Reported ≥ 1 objective outcome | Reported # participants lost to follow-up | Q score
Kinney, 1999 ^68^ | 1 | 2 | 1 | 2 | 2 | | 2 | 2 | 86
| 1 | 2 | 1 | 2 | 2 | | 2 | 2
Ware, 2002 ^73^ | 1 | 2 | 1 | 2 | 2 | | 2 | 2 | 86
| 1 | 2 | 2 | 2 | 2 | | 2 | 1
Zimmerman, 2004 ^81^ | 2 | 1 | 2 | 2 | 1 | | | | 86
| 1 | 2 | 2 | 2 | 2 | | 2 | 2
Wang, 2001 ^60^ | 1 | 1 | 2 | 2 | 0 | | 2 | 2 | 67
| 1 | 2 | 1 | 2 | 0 | 0 | 2 | 2
Hankins, 2005 ^72^ | 1 | 2 | 2 | 2 | 0 | | 2 | 2 | 67
| 1 | 1 | 1 | 2 | 0 | 0 | 2 | 2
de Montalembert, 1997 ^76^ | 0 | 2 | 2 | 2 | 1 | | 2 | 2 | 85
| 2 | 2 | 2 | 2 | 1 | | 2
Maier-Redelsperger, 1998 ^75^ | 2 | 2 | 2 | 2 | 0 | 1 | 2 | 2 | 77
| 1 | 2 | 1 | 2 | 0 | | 2 | 2
de Montalembert, 2006 ^48^ | 2 | 1 | 1 | 2 | 1 | | 2 | 1 | 71
| 2 | 1 | 1 | 1 | 2 | | 2 | 1
Ferster, 2001 ^58^ | 2 | 2 | 1 | 2 | 0 | 1 | 2 | 0 | 63
| 0 | 2 | 2 | 1 | 0 | | 2 | 2
Gulbis, 2005 ^82^ | 1 | 2 | 2 | 1 | 0 | | 2 | 1 | 54
| 1 | 2 | 1 | 1 | 1 | 0 | 1 | 1
el-Hazmi, 1992 ^45^ | 1 | 1 | 1 | 2 | 2 | 0 | 2 | | 57
| 1 | 1 | 1 | 1 | 1 | | 2 | 0
Charache. 1992 ^46^ | 0 | 2 | 2 | 2 | 1 | | 2 | 2 | 89
| 2 | 2 | 2 | 2 | 2 | | 2 | 2
Voskaridou, 1995 ^78^ | 0 | 1 | 2 | 2 | 0 | | 2 | 0 | 54
| 1 | 0 | 2 | 2 | 1 | | 2 | 0
Scott, 1996 ^77^ | 2 | 2 | 2 | 2 | 1 | | 2 | 2 | 93
| 1 | 2 | 2 | 2 | 2 | | 2 | 2
Loukopoulos, 1998 ^69^ | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | 23
| 0 | 1 | 1 | 1 | 0 | | 2 | 0
Olivieri, 1998 ^64^ | 2 | 2 | 2 | 2 | 2 | | 2 | | 88
| 1 | 1 | 1 | 2 | 2 | | 2
Hanft, 2000 ^57^ | 1 | 0 | 1 | 1 | 0 | 1 | 2 | | 31
| 0 | 0 | 1 | 0 | 0 | 0 | 2 | 0
Loukopoulos, 2000 ^74^ | 1 | 1 | 1 | 2 | 0 | 0 | 2 | 2 | 63
| 1 | 2 | 2 | 1 | 0 | | 2 | 2
Rigano, 2001 ^71^ | 1 | 2 | 1 | 1 | 0 | 0 | 2 | 2 | 70
| 0 | 2 | 2 | 2 | 2 | | 2 | 2
Chaine, 2001 ^66^ | 2 | 1 | 2 | 1 | 0 | | 2 | | 52
| 0 | 0 | 1 | 1 | 0 | 1 | 2
Al-Jam'a, 2002 ^70^ | 2 | 2 | 1 | 1 | 1 | | 2 | 2 | 89
| 2 | 2 | 2 | 2 | 2 | | 2 | 2
Ferguson, 2002 ^52^ | 2 | 1 | 1 | 1 | 0 | 1 | 2 | | 57
| 2 | 2 | 1 | 1 | 1 | 0 | 2 | 0
Cummins, 2003 ^61^ | 1 | 1 | 1 | 1 | 0 | 0 | 2 | | 37
| 1 | 0 | 1 | 1 | 0 | 0 | 2 | 0
Ware, 2004 ^67^ | 2 | 2 | 2 | 2 | 2 | | 2 | | 88
| 1 | 1 | 1 | 2 | 2 | | 2
Bakanay, 2005 ^51^ | 2 | 1 | 2 | 2 | 0 | 2 | 2 | 0 | 50
| 1 | 0 | 1 | 1 | 0 | 1 | 1 | 0
Vicari, 2005i ^80^ | 0 | 1 | 1 | 0 | 0 | | 1 | 0 | 25
| 0 | 1 | 1 | 0 | 0 | | 2 | 0
Khayat, 2006 ^47^ | 0 | 0 | 0 | 1 | 0 | | 2 | | 27
| 0 | 1 | 0 | 1 | 0 | | 2 | 0
Kratovil, 2006 ^62^ | 2 | 2 | 2 | 2 | 0 | 2 | 2 | | 73
| 2 | 1 | 1 | 1 | 0 | 2 | 2 | 1
Ataga, 2006 ^79^ | 2 | 2 | 1 | 0 | 0 | 0 | 2 | | 40
| 2 | 1 | 2 | 0 | 0 | 0 | 0 | 0
Svarch, 2006 ^50^ | 0 | 2 | 0 | 1 | 0 | | 2 | | 35
| 1 | 1 | 0 | 1 | 0 | | 1 | 0
Zimmerman, 2007 ^63^ | 2 | 2 | 2 | 2 | 0 | 0 | 2 | 0 | 73
| 2 | 2 | 2 | 1 | 1 | | 2 | 2
McKie, 2007 ^49^ | 2 | 1 | 1 | 1 | 0 | 0 | 2 | 1 | 50
| 2 | 1 | 1 | 1 | 0 | | 2 | 0
Harrod, 2007 ^56^ | 1 | 1 | 1 | 0 | 0 | 1 | 2 | | 39
| 1 | 1 | 1 | 0 | 0 | 0 | 2
Hankins, 2007 ^65^ | 0 | 1 | 1 | 1 | 0 | | 2 | 0 | 43
| 2 | 0 | 1 | 2 | 0 | | 2 | 0
Santos, 2002 ^59^ | 1 | 2 | 2 | 1 | 0 | 0 | 1 | | 47
| 0 | 2 | 2 | 2 | 0 | 0 | 2

Evidence Table 5a. Adequacy of Reporting in Observational Studies in Sickle Cell Disease

Surveys
Author, year | Study description | Inclusion or exclusion criteria described | Key characteristics of participants described | Completion Rate | Instrument Validated | Validity Discussed | Reliability Discussed | Q Score
de Montalembert, 1999 ^55^ | 2 | 0 | 1 | | 0 | 0 | 0 | 18
| 1 | 0 | 1 | | 0 | 0 | 0
Schultz, 2003 ^53^ | 2 | 1 | 0 | | 0 | 0 | 0 | 14
| 1 | 0 | 0 | | 0 | 0 | 0

* blank cells indicate “not applicable” response by one reviewer

Q = quality

Evidence Table 6. Patient Characteristics in Observational Studies of Hydroxyurea for Sickle Cell Disease

Author, year | Comparison group | N | Genotype, % | Haplotype, % | Mean age in years (SD) [range]* | Male, % | Race (%) | Clinical disease activity (SD) [range]
HUG-KIDS Cluster
Kinney, 1999 ^68^ | NR/NA | 84 | SS 100 | NR | 9.8; 9.1* [5–15] | NR | Black (100)
Ware, 2002 ^73^ | NR/NA | 68 | NR | NR | 9.5 | | NR
Zimmerman, 2004 ^81^ | NR/NA | 122 | SS 86; SC 5.7 Sβ^0^ thal 5.7; S/O-Arab 1.6 | NR | 11.1* [0.5 – 19.7] | 58 | NR
HUSOFT Cluster
Wang, 2001 ^60^ | NR/NA | 28 | SS 96; Sβ^0^ thal 4 | NR | 1.3* [0.5–2.3] | 57 | NR
Hankins, 2005 ^72^ | NR/NA | 21 | SS 95; Sβ^0^ thal 5 | NR | 3.4* [2.6–4.4] | 43 | Black (100)
French Cluster
de Montalembert, 1997 ^76^ | NR/NA | 35 | SS 94; Sβ^0^ thal 3; Sβ^+^ thal 3 | NR | 11* [3–20] | 74 | NR | Hospital days 29 [0–117]
Maier-Redelsperger, 1998 ^75^ | NR/NA | 29 | NR | Benin 9; Senegal 3; CAR 8 | 10.9 [4–19] | 72 | NR
de Montalembert, 1999 ^55^ | NR/NA | 101 | SS 98; Sβ^+^ thal 1; Sβ^0^ thal 1 | NR | 9.8 [2–20] | 55 | NR | One HIV^+^
de Montalembert, 2006 ^48^ | NR/NA | 225 | SS 94; SC 1.3; Sβthal 3.5; Hb-Punjab 0.8 | NR | 9.2 [1.42–19] | 61 | NR
Belgian Cluster
Ferster, 2001 ^58^ | NR/NA | 93 | SS 99; HB-Punjab 1 | NR | 7* [0.7 to 45] | 52 | Black (94) | 67 had ≥2 pain crises; 9 had stroke; 19 had prior ACS
Gulbis, 2005 ^82^ | NR/NA | 109 | SS 93; SC 3; Sβ^0^ thal 3 | NR | 6 [.75 – 19] | NR | NR | 99 had ≥ 2 pain crises, 21 had prior ACS, 7 had prior stroke, 1 with prior TIA
Others
el-Hazmi, 1992 ^45^ | NR/NA | 21 | SS 71; Sβ^0^ thal 28 | NR | [17–32] | NR | NR
Charache. 1992 ^46^ | NR/NA | 49 | SS 100 | Benin 61; Senegal, 9.3; CAR 25 | 27.6 | 55 | Black (100)
Voskaridou, 1995 ^78^ | NR/NA | 14 | Sβ^+^ thal 42; Sβ^0^ thal 58 | NR | 28.6 [19–48] | 64 | NR
Scott, 1996 ^77^ | NR/NA | 15 | SS 73; Sβ^0^ thal 13; Sα^+^ thal 13 | NR | 14 [(10–17) | 40 | NR
Loukopoulos, 1998 ^69^ | NR/NA | 44 | Sβ^+^ thal 34; Sβ^0^ thal 65 | NR | NR | NR | NR
Olivieri, 1998 ^64^ | NR/NA | 17 | NR | NR | 12.4 [5 – 18] | NR | NR | Transfusions, 1.8; (0.5)/yr; Chest syndrome, 1.3; (0.5) /yr; Hospitalized days 29.1; (4.8)/yr
Hanft, 2000 ^57^ | Adults with MPD and HU exposure | 12 | NR | NR | 62 | NR | NR
| Adults with SCD and short HU exposure | 15 | | | 29
| Children with SCD and no HU | 21 | | | 11
| Children with SCD and low HU exposure | 17 | | | 11
Loukopoulos, 2000 ^74^ | NR/NA | 69 | SS 20; Sβ^0^ thal 79 | All HbS was Benin | [17–50] | 58 | White (100)
Rigano, 2001 ^71^ | NR/NA | 22 | Sβ^0^ thal 76; Sβ^+^ thal 27 | Benin 100% | [29–53] | 68 | White (100) | Pain crises 7/yr (mean)
Chaine, 2001 ^66^ | NR/NA | 17 | SS 94; Sβ^0^ thal 6 | Benin 12.5; Senegal 2; CAR 3 | 27.1 [19–51] | 53 | Black (100) | 2 with leg ulcers
Al-Jam'a, 2002 ^70^ | NR/NA | 27 | NR | NR | 21.3 [10–36] | 67 | NR | Yearly pain crises 6.5 (2.8); Days in hospital 34 (26)
Ferguson, 2002 ^52^ | HU at least 24 months | 30 | SS 100 | NR | [20–58] | 43 | NR | Transfusions 5/yr; Hospitalizations 3.3/year
| HU less than 24 months | 30 | NR | NR | [19–54] | 30 | | Transfusions 5.8/yr; Hospitalizations, 5.7/yr
Schultz, 2003 ^53^ | Patients with cancer | 49 | SS 63; SC 22; Sβ thal 14 | NR | 34* [1.2–62] | NR | NR
| Patients on HU who developed cancer | 3 | NR | NR
Cummins, 2003 ^61^ | HU | 15 | SS 93 | NR | 33 | 67 | NR
| CBT | 21 | SS 57; SC 29 | NR | 30.9 | 33
Ware, 2004 ^67^ | NR/NA | 35 | SS 94; Sβ^0^ thal 3; S/O Arab 3 | NR | 11.9 [3 – 19.9] | 66 | NR | Stroke incidence, 5.7 per 100 patient years
Bakanay, 2005 ^51^ | NR/NA | 226 | NR | NR | NR | 51 | NR
Vicari, 2005i ^80^ | NR/NA | 22 | SS 100 | homo Bantu 41; homo Benin 18; hetero Bantu-Benin 31 | 25.6 [18–46] | 32 | NR
Khayat, 2006 ^47^ | NR/NA | 8 | NR | NR | [7–20] | NR | NR
Kratovil, 2006 ^62^ | HU | 24 | SS 100 | NR | 9.9 [1.7–16] | 58 | NR | Average of Max TCD velocity 125 ( 32.3) cm/sec2
| No HU | 24 | NR | NR | 9.4 [2.1–16] | 67 | | Average of Max TCD velocity, 128.9 cm/sec2 range 79–220
Ataga, 2006 ^79^ | HU (with PHTN) | 9 | SS 74: SC 12; Sβ^0^ thal 5; Sβ^+^ thal 9 (PHTN & no PHTN groups combined) | NR | 42.3 (11) | 42 | NR | History of acute chest syndrome, 88%; Crises in past year, 3.0 (3.6); History of stroke, 15%
| HU (No PHTN) | 32 | | | 38.4 (12) | 38 | | History of acute chest syndrome, 82%; Crises in past year: 3.8 (4.3); History of stroke, 8%
Svarch, 2006 ^50^ | NR/NA | 51 | SS 100 | NR | [4–18] | NR | NR | Pain crises 3 [0–4]; Transfusions 3.9 [0–8] Chest syndrome [0–3]; Hospitalizations admissions 4 [0–6]
Zimmerman, 2007 ^63^ | Increased TCD velocities | 37 | NR | NR | 6.8; 5.6* | NR | NR | Median RMCA, 162 cm/sec2; Median LMCA, 166 cm/sec2
McKie, 2007 ^49^ | HU no microalbuminuria | 19 | SS 100 | NR | NR | NR | NR
| HU and microalbuminuria | 9 | NR | NR
| ACE-Inhibitor for microalbuminuria | 9 | NR | NR
| Usual care | 154 | NR | NR | NR | NR | NR
Harrod, 2007 ^56^ | HU, no splenectomy | 46 | SS 100 | NR | 12.1 | NR | NR
| No HU, no splenectomy | 58 | NR | NR | 4.6
| HU with splenectomy | 11 | NR | NR | 10.7
| No HU with splenectomy | 10 | NR | NR | 8.7
Hankins, 2007 ^65^ | NR/NA | 52 | SS 99; Sβ^0^ thal 1 | NR | 9.9* [3–17.6] | 65 | Black (98)
Santos, 2002 ^59^ | HU | 21 | SS 14; Sβ^0^ thalassemia 7 | NR | Mean, 11.7 [3–22] | 14 | NR

* Median age reported instead of mean

+ ACE = Angiotensin-Converting Enzyme; ACS = Acute chest syndrome; CAR = Central African Republic; CBT = cognitive behavioral therapy; Hb = hemoglobin; hetero = heterozygous; homo = homozygous; HU = hydroxyurea; HUG-KIDS = Safety of Hydroxyurea in Children With Sickle Cell Anemia; HUSOFT = Hydroxyurea Safety and Organ Toxicity; LMCA = left main coronary artery; MPD = myeloproliferative disorders; NA = not applicable; NR = not reported; PHTN = pulmonary hypertension; RMCA = right middle cerebral artery; Sβ thal = Sickle β thalassemia; Sβ^0^ thal = Sickle β^0^ thalassemia; S/O-Arab= hemoglobin SO-Arab; Sα thal = Sickle α thalassemia; SC= Sickle-Hemoglobin C Disease; SCD = Sickle Cell Disease; SD = standard deviation; SS = Sickle Hemoglobin SS Disease; TCD = transcranial Doppler; TIA = transient ischemic attack

Evidence Table 7. Efficacy Results of Randomized Controlled Trials in Sickle Cell Disease

Author, year | Intervention | N | Mean durations of drug | Deaths, n (%) | Hb F, % ^±^ SD | F cells, % ^±^ SD | Hemoglobin, g/dl | MCV, fl ^±^ sd | Reticulocyte count, k/ul | Weight change, kg (%) | Change in peak power, watts ^±^ sem | Pain crises & admissions | Transfusion
| | | Mean duration of followup
MSH
Ballas, 2006 ^42^ | HU | 141 | 24 months
| Placebo | 136
Steinberg, 2003 ^43^ | HU | 152 | 7.7 years | 36 (23.7) | | | | | | | | Stroke, 8*
| Placebo | 147 | 7.4 years | 39 (26.5) | | | | | | | | Stroke, 6*
Moore, 2000 ^22^ | HU | 152 | 24 months
| Placebo | 147 | NR
Hackney, 1997 ^41^ | HU | 10 | 24 months | | | | | | | 3.2^±^ 0.8^†^ | 104.9^±^ 31
| Placebo | 14 | 18 months | | | | | | | 1.8^±^ 0.8^‡^ | 57.7^±^ 20
Steinberg, 1997 ^40^ | HU | 152 | 24 months | | 3.6^±^ 5.4^§^ | 15.2^±^ 17.3^§^ | | 9.7^±^ 11.2^§^ | 97^±^ 107^§^
| Placebo | 147 | 28 months (range, 21–38) | | -0.4^±^ 2^§^ | 2.3^±^ 7.1^§^ | | -0.4, ^±^ 4.8^§^ | 21^±^ 72^§^
Charache, 1996 ^39^ | HU | 152 | 24 months | 2 | | | | | | | | | 55^‖^
| Placebo | 147 | 28 months ^±^ 6 | 5 or 6 | | | | | | | | | 79^¶^
Charache, 1995 ^21^ | HU | 152 | 24 months | | 8.6^±^ 6.8 | | 9.1^±^ 1.5 | | 231^±^ 100 | (3) | | ACS, 25^#^ | 48**
| Placebo | 147 | 28 months | | 4.7^±^ 2.2 | | 8.5^±^ 1.3 | | 300^±^ 99 | (6) | | ACS, 51^††^ | 73^‡‡††^
Other controlled trial
Ferster, 1998 ^44^ | HU | 22 | 6 months | | 10.8^§§§^ | | 0.4^§‖‖^ | 10.41^§§§^ | -46^§§§^ | | | 1.1^¶¶^
| Placebo | 22 | 22 months | | | | | | | | | 2.8^##^

* Stroke

± Mean SEM, p = <0.005

± (Mean SEM)

± Change from baseline, mean SD where applicable.

‖ Patients, P = 0.002, RBC units transfused, 423 P=0.002

¶ Patients, RBC units transfused, 670.

# p <0.001, Median time to first crisis, 3 months, p < 0.01, Pain crises per year, 2.5 (OR 0.6–7).

** p <0.001, RBC units transfused, 336.

†† Median time to first crisis, 1.5 months. Pain crises per year, 4.5 (IQR 2–10.2)

‡‡ RBC units transfused, 586

§§ p < 0.001

‖‖ p = NS

¶¶ p = 0.016, Days hospitalized, 3.6, p = 0.0027, hospitalizations per year

## Days hospitalized, 11.7, hospitalizations per year

ACS=acute chest syndrome; HbF = Fetal hemoglobin; HU=hydroxyurea; IQR = interquartile range; MCV = mean corpuscular volume; MSH = Multicenter Study of Hydroxyurea for Sickle Cell Anemia; NR = not reported; OR = odds ratio; RBC = red blood cells; SD = standard deviation; SEM = standard error of the mean.

Evidence Table 8. Efficacy and Effectiveness Results of Observational or Single Arm Studies of Hydroxyurea in Sickle Cell Disease

Author | Patients/design | Study arm | N | Hb F%* | %F cells* | Hemoglobin (g/dl) | MCV (fl) | WBC count (/ul) | Pain crises* | Hospital admissions* | Comments
HUG-KIDS
Kinney, 1999 ^68^ | Children-prospective | HU | 84 | 17.8 (7.2)^†^ | 66.5 (19.6)^†^ | 9 (1.4)^†^ | 101.3 (10.2)^†^ | 9,200 (3200)^†^ | | | Hematological effects were attained by 6 months (even before MTD). There was little difference between 6 and 12 month data. Continued weight gain and linear growth.
| | Baseline (pre-HU) | | 7.3 | 34.6 (17.8) | 7.8 | 85.9 (6.6) | 13,600
Ware, 2002 ^73^ | Children-prospective | HU | 68 (53 with sufficient data) | Median = 17.6, [2.9–32.4] | | | | | | | HbF% was predicted by HbF% at baseline (p=.001) and Hb at baseline (p=0.01); HbF% was negatively associated with # of pills returned (p=0.02), postively with change in Hb (p<0.0001), MCV (p=0.01) and decline in reticulocytes (p=0.01), and decline in white blood count (p=0.006).
| | Baseline (pre-HU) | | 6.7 | | 7.7 | 85.7 | 14,000
Zimmerman, 2004 ^81^ | Children-prospective | HU | 122 | 19.7( 8.5)^‡^ | | 9.7(1.3)^‡^ | 105.8 (13.8)^‡^ | 7.0 | | | Efficacy (in Hb, MCV, % Hb F, WBC count, ANC, reticulocyte, bilirubin) maintained over 7 years of follow-up.
| | Baseline (pre-HU) | | 7.6 | | 8.2 | 84.4 (8.5) | 12,400
HUSOFT
Wang, 2001^60^ | Children-prospective | HU | 28 | 20.3 (4.9) | 76.2 (12.4) | 8.8 (1.2) | 90 (9.6) | 10,100 (3,200) | | | Outcomes are for 21 patients who completed 2 years of treatment (not necessarily on MTD).
| | Baseline (pre-HU) | | 21.8 (7.8) | 80.6 (14.1) | 8.5 (1.2) | 81.7 (8.0) | 12600 (4,400)
| | CSSCD | | 10.9 (7.9) | 65.4 (11.2) | 7.7 (1.0) | 84.1 (10.1) | 14,300 (2,400)
Hankins, 2005 ^72^ | Children-prospective | HU | 21 | 23.7 (7.4)^‡^ | 82.6 (7.9)^‡^ | 9.1 (1.4)^‡^ | 95.1 (10.4)^‡^ | 10,100 (5,000)^‡^ | 33.8/100 pt-yr compared to 32.4/100 pt-yr in CSSCD^§^ | | Outcomes are for 17 children after 4 years of therapy.
| | Baseline (pre-HU) | | 21.8 (7.8) | 80.6 (14.1) | 8.5 (1.2) | 81.7 (8.0) | 12,600 (4,400)
French Cluster
de Montalembert, 1997 ^76^ | Children-prospective | HU | 35 | 13.7 [3.2–27.0]^†^ | | 9 (1.4) p= 0.03 | | | | | All but two patients had decreased frequency or termination of crises. No clear difference in weight or height velocity.
| | Baseline (pre-HU) | | 4 [0.85–13.9] | | 8.4 (1.2)
Maier-Redelsperger, 1998 ^75^ | Children-prospective | HU | 29 | 13 (9.4) | 54.2 (22.1) | 9.1 (0.9) | 101.8 (15.9)
| | Baseline (pre-HU) | | 4 [0.85–13.9] | 24.4 | 8.4 (1.2) | 84.5
Belgian Cluster
Ferster, 2001 ^58^ | Children-prospective | HU | 93 | 16.7(10.6)^‖^ | | 8.8 (1.2)^‖^ | 94 (11) ^‖^ | | | 1.06 / pt-yr | Acute chest were 3.5/100 pt-yr, with no strokes during study.
| | Baseline (pre-HU) | | 7.3 | | 8.2 | 91 [70–118] | | | 2.76 (2.3) / pt-yr
Gulbis, 2005 ^82^ | Children-prospective | HU | 70 | 1.4 g/dl (HbF) | | 8.7 [6.8–13] at 3 years | 91[70–118] | | 2.2 / pt-yr that required hospitalization | 1.38 / pt-yr | There were 426 total patient years of follow-up. Hematological outcomes at 3 years (n=70) were 1 stroke and 5 transient ischemic attacks (1.3/100 pt-yrs).
| | Baseline (pre-HU) | 109 | 0.3 g/dl (HbF) | | 8.2 [6.7–10] | 83 [68–113] | | | 3.2 (2.7) / pt-yr
Others
el-Hazmi, 1992 ^45^ | Adults-prospective | HU | 21 | 19.8 (4)^†^ | | NR ^†^ | NR^†^ | 6,629 (2603)^†^ | | | P-value relative to baseline
| | Baseline (pre-HU) | | 11.8 (3.5) | | | | 14,0667 (6,716)
Charache. 1992 ^46^ | Adults-prospective | HU (at MTD) | 32 completed | 15 (6)^†^ | 73 (17)^†^ | 9.7 (1.8) ^†^ | 117 (15)^†^ | 8400 (1400) ^†^ | 1.3 (2) / 6-months [0 –9]^‖^ | | Mean 4.3 kg weight gain^†^
| | Baseline (pre-HU) | 49 | 4 (2) | 28 (14) | 8.4 (1.4) | 94 (8) | 13,400 (3200) | 4 [0–20]/6 months
Voskaridou, 1995 ^78^ | Adults-prospective | HU | 14 | 22.9 (7.7) | | 9 (1.3) | 95 (14.1)
| | Baseline (pre-HU) | | 3.6 (2.1) | | 9.0 (1.2) | 71.9 (5.7)
Scott, 1996 ^77^ | Children-prospective | HU | 15 | 15.2 (9.8,) [4.1–31] ^¶^ | | 9.5 (1.5) [7.7–13.1] | 100 (15) [80–127)^†^ | | | 3/yr (4)
| | Baseline (pre-HU) | | 6.9 (6.2) | | 8.2 (1.0) | 85 (11) | | | 7/yr(2.4)
Loukopoulos, 1998 ^69^ | Adults-retrospective | HU | 44 | 23.1 (9.2) | | 9.3 | 98.1 (15)
| | Baseline (pre-HU) | | 6.7(4.7) | | 8.9 | 75.7 (11)
Olivieri, 1998 ^64^ | Children-prospective | HU | 17 | 16.7 (1.8) | | 10.2 (3.6) | 104 (3) | | 1.2/yr(0.4) | 1.7/yr (2.0) | Acute chest syndrome rate declined from 1.3/yr to 0.2/yr. No difference in number of pitted red blood cells (n=12 children) was observed.
| | Baseline (pre-HU) | | 7.6 (1.6) | | 8.9 (4.3) | 87 (7) | | 3.1/yr(0.5) | 6.7/yr (2.8)
Loukopoulos, 2000 ^74^ | Adults-prospective | HU | 69 | Hematological results were reported stratified by sex and by genotype at baseline, also at maximum HbF during first 6 months and maximum HbF during whole study. | | | | | | | Mean clinical severity score of 81.7 over 12,018 pt-weeks was down from baseline score of 1182 (arbitrary scale).
Rigano, 2001^71^ | Adults-prospective | HU | 22 | 25.2 (5.2)^‡^ | | 10 (1.5) | 96.4 (7.2) ^‡^ | 10,200 (3,900) | 1.1 (1.8)/yr median = 0.5^‡^ | 0.5 (1.6)^†^; hospital days 1.2 (2.3) ^†^
| | Baseline (pre-HU) | | 7.5 ( 5.3) | | 6 (1.3) | 73.9 | 11,400 (3900) | 7 /yr median = 9 (all crises including pain) | hospital days 22.4
Al-Jam'a, 2002 ^70^ | Adults-Children-prospective | HU | 27 | 25.7 (7.3) median= 25^#^ | | 10.7 (1.4) median= 10.8^#^ | | 6,260 (2,580) median 5,600^#^ | | 0.93 (2.2) median= 0^†^; hospital days 5.1 (13.5) median 0^#^
| | Baseline (pre-HU) | | 12.6 (5.4) | | 9.71 (1.2) | | 8,990 (3,480) | 6.5/yr(2.8) | hospital days 33.9 (26.1)
Ferguson, 2002 ^52^ | Adults-retrospective/effectiveness | HU at least 24 months | 30 | | | | | | | 2.1 /yr p=.04 relative to baseline | 14 patients were treated for 48 months. Between baseline and year 4: admissions decreased from 3.56 to 1.64 /yr, transfusions 8.64 to 3.00/yr.
| | Baseline (pre-HU) | | | | | | | | 3.1/yr
| | HU less than 24 months | 30 | | | | | | | 4.8/yr p=0.49 relative to baseline
| | Baselinere-HU) | | | | | | | | 5.7 /yr
Cummins, 2003 ^61^ | Adults-prospective with comparison group | HU | 15 | | | | | | 1.4 /yr (2.1)^#^ | 1.1/yr (2.4) | Significant improvement in General Health perception (SF36) over CBT group
| | CBT | 21 | | | | | | 4.3/yr (4.3) | 0.9/yr (1.2)
Ware, 2004 ^67^ | Children-prospective | HU | 35 | 18.6 (6.6) | | 9.2(1.4) | 112(9) | 7300 (2500) | | | Data collected on two groups; patients initiating HU after an abrupt halt to transfusion therapy, and patients initiating HU before transfusion therapy was completely halted. Pooled data was presented here. Stroke recurrence rate 5/7/100 pt-yrs (7 children, 4 of whom were noncompliant with HU).
Bakanay, 2005 ^51^ | Children-retrospective | HU | 226 | | | | | | | | Very little description of study population and treatment, also had concern about confounding by indication.
Vicari, 2005i ^80^ | Adults-prospective | HU | 22 | 10.2 (5)** | | 8.6(1.1)^‡^ | | | | | Outcomes reported by haplotype.
| | Baseline (pre-HU) | | 5 (3) | | 7.9 ( 0.9)
Kratovil, 2006 ^62^ | Children-prospective with a comparison group | HU | 24 | 11.79, [3.8 – 25.4]^††^ relative to untreated | | 8.2 [5.2 –10.6] ^‡‡^ relative to untreated | | | | | Mean of maximum TCD =111.2 cm/sec
| | No HU | | | | | | | | | Mean of maximum TCD =124 cm/sec
Ataga, 2006^79^ | Adults-prospective | HU (with PHTN) | 9 | | | | | | | | In patients with PHTN, 9/26 (35%) were on HU. In patients without PHTN, 32/50 (65%) were on HU.
| | HU (No PHTN) | 32
Svarch, 2006 ^50^ | Children-retrospective | HU | 51 | 12.4 (7.9) ^†^ | | 8.5 (1) p=.0001 | | 9,800 (2,100) p=0.12 | Median 0.8/yr [0–2] | 0.5 [0–4] | Resource-poor environment
| | Baseline (pre-HU) | | 6.4 | | 7.8 | | 10,900 | Median 3/yr | 4 [0–6]
Zimmerman, 2007 ^63^ | Children-prospective | Patients with increased TCD velocities | 37 | 22.7 (7.9) median= 23.3 ^†^ | | 9.4 (1.1) median= 9.4 ^†^ | 104 (9) median ^†^ | | | | Significant decline in TCD of RMCA, LMCA, RACA, LACA, and LPCA, but not RPCA. Stroke rate on treatment 0.52/100 pt-years, RMCA on treatment 134 cm/sec, p<.0001.
| | | | 10.3 | | 7.8 | 86 (8) | | | | RMCA 162 cm/sec
McKie, 2007 ^49^ | Children-retrospective | HU with no microalbuminuria | 19 | | | | | | | | 16/17 remained free from microalbuminuria during treatment
| | HU + microalbuminuria | 9 | 19.8 (21.5) n=7 | | 8.6 (1.0) | 104.7 (7.1) | | | | 4 of 9 normalized microalbuminuria during treatment
| | HU + microalbuminurea atbaseline | 9 | 8.6 (1.0) | | 8.0 (1.4) | 92.1 (7.0)
| | Baseline (pre-HU) | 154
Harrod, 2007 ^56^ | Children-cross sectional | HU, no splenectomy | 46 | | | | | | | | Mature reticulocytes with Howell-Jolly bodies: 3533 ± 2665
| | No HU, no splenectomy | 58 | | | | | | | | 1263 ± 1193
| | HU with splenectomy | 11 | | | | | | | | 4984 ± 2037
| | No HU with splenectomy | 10 | | | | | | | | 2101 ± 945
Hankins, 2007 ^65^ | Children-prospective | HU | 52 | | | | | | | | 6 patients had recovery of splenic function; 24/25 had stable brain MRIs
Santos, 2002 ^59^ | Children-prospective | HU | 21 | 15.1^§§^ | | | | | | | 10 patients had improvement in splenic function

* Mean, (SD) [range] unless otherwise noted

† p ≤ 0.0001

‡ p ≤ 0.001

§ p ≤ not significant

‖ p ≤ 0.01

¶ p ≤ 0.002

# p ≤ 0.005

** p = 0.0002

†† p ≤ 0.00001

‡‡ p = 0.057

§§ Change from baseline

ANC = absolute neutrophil count; CBT=cognitive based therapy; CSSCD= Cooperative Study of Sickle Cell Disease; Hb = hemoglobin; HbF = fetal hemoglobin; HTN=hypertension; HU = hydroxyurea; HUG-KIDS = Safety of Hydroxyurea in Children With Sickle Cell Anemia; LACA=left anterior cerebral artery; LMCA = left main coronary artery; LPCA= left posterior cerebral artery; MCV = mean corpuscular volume; MRI = magnetic resonance imaging; MTD = maximum tolerated dose; NR = not reported; PHTN = pulmonary hypertension; pt-yr = patient-year; RACA=right anterior cerebral artery; RMCA = right middle cerebral artery; RPCA = right posterior cerebral artery; SCD = sickle cell disease; SD = standard deviation; TCD = transcranial Doppler; WBC = white blood cell.

Evidence Table 9. Description and Results of Studies (Cohort with Comparison Arm) Focusing on Biomarkers in Hydroxyurea Treatment of Sickle Cell Disease

Author, year | Location | Inclusion & exclusion criteria | Intervention | Starting dose: Titration | Planned treatment duration | Outcome | Result | Outcome | Result | Outcome | Result
Athanassiou, 2006 ^85^ | Europe | Inclusion: Sβ^0^ thal, Sα+ thal | HU | | 60 months | Index of rigidity (IR) | 31.9± 12.2* | Mean elastic shear modulus (u × 10ˆ-3 dyn/cm) | 15± 1.3^†^
| | | SCD no HU | | | | 46.1± 13.08 | | 21.1± 2.1
| | | NO SCD or HU | | | | 13.15± 0.5
Iyamu, 2005 ^86^ | North America | Inclusion: Age 8–21; SCA; in steady state | HU steady-state | 15–30 mg/kg/d | Cross-sectional | Hb F % | 13.8 | Nitric oxide synthase (nmol/ml/min) | 0.50 | Arginase (U/nmol/10ˆ8 cells ± SEM) | 1.36± 0.20^‡^
| | Exclusion: Transfusion in last 6 months; smoking; SA | No HU steady-state | No HU | | | 6.8 | | 0.27 | | 3.31± 0.29
| | | African American Hb AA | No HU | | | | | 0.32 | | 0.23
Nahavandi, 2002 ^87^ | North America | Inclusion: SCA | HU | 1200 mg/d | 35 | Hb F% (range) | 17 (6.7–28) | Cyclic GMP (pmol/ml ± SEM) | 2.45± 0.32 | Nitric oxide metabolites (microM ± SEM) | 29± 2.5
| | Exclusion: Transfusion within 3 months; significant renal insufficiency; infection; PHT | Non-HU steady state | No HU | | | 3.6, (1.7–6)^§^ | | 1.75± 0.42 | | 19± 1.8^§^
| | | HU during VOC | 1200 mg/d | | | 19 (7–31) | | 2.56± 0.3 | | 32± 5
| | | Non-HU during VOC | No HU | | | 4.2 (1.5–6.7)^§^ | | 1.56± 0.1^§^ | | 17± 1.7^§^
Lapoumeroulie, 2005 ^88^ | Europe | Inclusion: Children, SCA in steady-state | Clinical events (8 on HU, 10 untreated) | | > 12 months | Endothelin-1 (pg/ml ± SEM) | 1.32± 0.17
| | | steady state, No HU | | | | 0.65± 0.11
| | | steady state, HU | | | | 0.37± 0.05^†^
| | | Healthy AA | | | | 0.65± 0.07
Tavakkoli, 2004 ^89^ | North America | Inclusion: SCA | HU | 1000–1500mg: N/A | | TNF-α (pm/ml) | 4.89
| | Exclusion: Transfusion in last 3 months | Steady state condition, not on HU | | | | 3.78
| | | VOC, on HU | 1000–1500mg: N/A | | | 6.45
| | | VOC, not on HU | | | | 5.86
Teixeira, 2003 ^92^ | South America/Mexico | Inclusion: SCA, S β+ thal; S βo thal; S α+ thal; SC; Age >12 | HU | | 2 to 60 months | Hb F (%) | 14.2± 8.3^§^ | Hb (g/dl) | 9.6± 2.2^§^
| | | No HU | | | | 8.8± 4.1 | | 8.1± 0.9
Heeney, 2003 ^90^ | North America | Inclusion: Children; SCA; S β+ thal; S βo thal | UGT1A 6/6 | 15–20 mg/kg/day: every 8 weeks to max of 30–35 mg/kg/day | at least 12 months | Hb F (%)^‡^ | 16.4 | Hb (g/dl)^‡^ | 1.7 | Total bilirubin (mg/dl)^‡^ | -1.4
| | Exclusion: HU before age 5 years; No labs before HU; <12 months of HU; Unknown or rare UGT1A genotype | UGT1A 6/7 | 15–20 mg/kg/day: every 8 weeks to max of 30–35 mg/kg/day | | | 12.1 | | 1.5 | | -1.3
| | | UGT1A 7/7 | 15–20 mg/kg/day: every 8 weeks to max of 30–35 mg/kg/day | | | 13.5 | | 1.9 | | -2.8
Nahavandi, 2003 ^91^ | North America | Inclusion: Age 18–48; SCA | HU, no VOC | 1000–1500 mg/day | | Venous oxyhemoglobin (%) | 65 | Venous reduced Hb (%) | 28 | Nitric Oxide Metabolites (μM) | 17 ± 9^§^
| | Exclusion: ACS; transfused in last three months; renal insufficiency; infection; hypoxemia | No HU no VOC | | | | 60 | | 36
| | | HU and VOC | 1000–1500 mg/day | | | 81 | | 13
| | | No HU, VOC | | | | 73 | | 22

* p = 0.02

† p = 0.03

‡ p < 0.001

§ p < 0.05

0 AA = African American; ACS = acute chest syndrome; GMP = granual membrane protein; Hb = hemoglobin; HU = hydroxyurea; IR = index of rigidity; N/A = not applicable; PHT = pulmonary hyptertension; S β+ thal = S β+ thalassemia; S β thal = S β thalassemia; S α+ thal = S α+ thalassemia; SA = Substance abuse; SC = Sickle-Hemoglobin C Disease; SCA = sickle cell anemia; SCD = Sickle cell disease; SEM = standard error of the mean; TNF-α = tumor necrosis factor alpha; VOC = vaso-occlusive crisis.

Evidence Table 10. Patient Characteristics in Studies of Biomarker Studies on Treatment with Hydroxyurea in Sickle Cell Disease^†^

Author, year | Intervention | N | Age, mean (SD) [range]* | Male, n (%) | Genotype/ haplotype (%) | Last observation
Athanassiou, 2006 ^85^ | HU | 22 | Median, 30; [20–46] | (14) | NR | NR
| SCD no HU | 14 | Median, 32; [25–42] | (5)
| NO SCD or HU | 5 | Mean, similar age | (40)
Iyamu, 2005^86^ | HU, steady state | 23 | 13.5 [9–21] | NR | SS, (100) | Cross-sectional—once
| No HU, steady state | 12 | 12.5 [(8–19] | | SS, (100)
| African-American Hb AA | 10 | 15.6 [11–21] | | Hb AA (100)
Nahavandi, 2002 ^87^ | HU | 12 | 32 [18–47] | 9 | SS, (100) | NR
| Non-HU steady state | 26 | 34 [18–53] | 8
| HU during VOC | 14 | 34 [18–48] | 8
| Non-HU during VOC | 12 | 31 [18–45] | NR
Lapoumeroulie, 2005 ^88^ | Clinical events; Hb SS 8 HU, 10 none | 18 | [2.9–13.2] | NR | SS, (100) | NR
| Hb SS, no HU | 17 | [3.0–14.9]
| Hb SS, HU | 16 | [3.5–15.1]
| Nl AA, controls none | 26 | [2.6–15.8]
Tavakkoli, 2004 ^89^ | HU | 10 | 32 [18–47] | NR | SS, (100) | NR
| Steady state condition, not on HU | 10 | 34 [15–53]
| VOC, on HU | 10 | 34 [18–48]
| VOC, not on HU | 10 | 31 [18–45]
| No HU | 30
Teixeira, 2003 ^92^ | HU | 31 | NR | NR | NR | NR
| No HU | 30
Heeney, 2003 ^90^ | HU UGT1A 6/6 | 17 | Mean, 11.4 | 13 | NR | At least 12 months
| HU UGT1A 6/7 | 24 | Mean, 11.3 | 15
| HU UGT1A 7/7 | 18 | Mean, 12.6 | 11
Nahavandi, 2003 ^91^ | HU | 12 | 32 [18–47] | 9 | SS, (100) | NR
| HU untreated, with VOC | 12 | 31 [18–45] | 8
| HU treated, with VOC | 14 | 34 [18–48] | 8
| HU untreated control, no VOC | 31 | 34 [18–53] | NR

* Unless otherwise specified

† Recruitment start and end dates as well as race of patients were unreported for all studies in this table.

AA = African American; Hb = hemoglobin; HU = hydroxyurea; NR = not reported; SCD = sickle cell disease; SD = standard deviation; SS = Sickle Hemoglobin SS Disease; VOC = vaso-occlusive crisis

Evidence Table 11. Adequacy of Reporting in Biomarker Studies in Sickle Cell Disease*

Author, year | Source population | Inclusion criteria | Baseline characteristics | Intervention | Adherence | Adjustment when reporting outcome comparisons | Objective outcome | Losses to follow-up | Q Score
Athanassiou, 2006 ^85^ | 0.5 | 0.5 | 1 | 0 | 0 | 0 | 2 | | 29
Iyamu, 2005 ^86^ | 0 | 0.5 | 1 | 1 | 0 | 0 | 2 | | 32
Nahavandi, 2002 ^87^ | 0.5 | 1 | 1 | 1 | 0 | 0 | 2 | | 39
Lapoumeroulie, 2005 ^88^ | 1 | 0 | 1 | 0 | 0 | | 2 | | 29
Tavakkoli, 2004 ^89^ | 1 | 1 | 1.5 | 1.5 | | 0 | 2 | | 58
Teixeira, 2003 ^92^ | 1 | 0 | 0.5 | 0.5 | 0 | 0 | 1.5 | | 23
Heeney, 2003 ^90^ | 1 | 2 | 1.5 | 2 | 0 | 0 | 2 | | 57
Nahavandi, 2003 ^91^ | 1.5 | 1.5 | 2 | 1 | 0 | 0 | 2 | 0 | 50

* Blank cells represent categories that were not applicable to the question

Q = quality

Evidence Table 12. Toxicity Results in Randomized Controlled Trials of Hydroxyurea Treatment in Sickle Cell Disease

| | | Mean drug duration
Author, year | Intervention | N | Mean follow-up duration | Death, n (%) | Thrombocytopenia | Netropenia, % | Absolute neutrophil count, ul +/- SD | % GI disturbance, | % Rash or Nail changes | Lower extremity ulcers | Other
MSH
Steinberg, 2003 ^43^ | HU | 152 | NR | 36 (23.7) | | | | | | | Malignancy, 1
| | | | | | | | | | | Sepsis/Infection, 18
| | | | | | | | | | | Hepatic Failure, 3
| | | 7.7 years | | | | | | | | Renal Failure, 14
| Placebo | 147 | NR | 39 (26.5) | | | | | | | Malignancy, 1
| | | | | | | | | | | Sepsis/Infection, 20
| | | | | | | | | | | Hepatic Failure, 10
| | | 7.4 years | | | | | | | | Renal Failure, 14
Steinberg, 1997 ^40^ | HU | 152 | 24 months | | | | 1,900* ± 2,400
| Placebo | 147 | 28 months (range, 21–38) | | | | 400 ± 2,200
Charache, 1996 ^39^ | HU | 152 | 24 months | (2) | | 66 | | 59 | 25 | 15 | Hair Loss, 18
| | | | | | | | | | | Fever, 91
| | | | | | | | | | | Aplastic crisis, 1
| | | | | | | | | | | Aseptic Necrosis, 9
| | | | | | | | | | | Lymphadenopathy, 45
| | | | | | | | | | | Bleeding Tendency, 7
| Placebo | 147 | 28 months ± 6 | (6) | | | | 58 | 25 | 17 | Hair Loss, 28
| | | | | | | | | | | Fever, 96
| | | | | | | | | | | Aplastic crisis, 5
| | | | | | | | | | | Aseptic Necrosis, 9
| | | | | | | | | | | Lymphadenopathy, 56
| | | | | | | | | | | Bleeding Tendency, 3
Charache, 1995 ^21^ | HU | 152 | 24 months | (2) | 4 | | 4,900± 2,000 | | | 15 | Hemoglobin > 12.8 g/dl, 11
| | | | | | | | | | | Platelets >800,000/ul, 4
| Placebo | 147 | 28 months | (5) | 5 | | 6,400± 2,000 | | | 17 | Hemoglobin > 12.8 g/dl, 1
| | | | | | | | | | | Total Bilirubin > 10 mg/dl, 4
Belgian Study
Ferster, 1998 ^44^ | HU | 25 | 6 months | | 2 | | | | | | No clinically significant toxicity
| | | 22 months | | 0

* Change from baseline, mean ± SD

GI = gastrointestinal; HU = hydroxyurea; NR = not reported; SD = standard deviation

Evidence Table 13. Toxicities of Hydroxyurea Reported in Single Arm Studies in Sickle Cell Disease

Author | Group | N | Primarily toxicity study | Deaths, n (per pt/yr) | Neutropenia | Thrombocytopenia | Leukemia | Leg ulcers | Rash or nail changes | Other
HUG-KID
Kinney, 1999 {#2977} | HU | 84 | Yes | | 56 with ANC< 2000/μl | 7 | | | 5
Zimmerman, 2004 {#2960} | HU | 122 | | (2/ 455) | | | 0 | | | No increase in the acquired illegitimate VDJ rearrangements.
HUSOFT
Wang, 2001 {#2964} | HU | 28 | | 1 | 17 with ANC< 1500/μl | 1 with <80,000/μl
| | | | | 6 with ANC< 500/μl
Hankins, 2005 {#2954} | HU | 21 | | 1 | 21 episodes in 10 patients in year 3, 21 episodes in 9 patients in year 4 | 2 in year 5 | | | | Severe anemia 3 times in 3 patients in year 3; 4 times in 1 patient in year 4.
| | | | | | 1 in year 6
French Cluster
de Montalembert, 1997 {#2980} | HU | 35 | | | | | | | 5
de Montalembert, 1999 {#2976} | HU | 101 | Yes | | 2 with ANC 500–1000/μl | 4 with 90–100,000/μl | 1 | 1 | 8
| | | | | 3 with ANC 1000–1500/μl
de Montalembert, 2006 {#2962} | HU | 225 | Yes | 1 | 8 | 8 | 1 (same patient as in earlier study {#2980}) | | | 81 patients discontinued therapy, mostly for lack of efficacy
Belgian Cluster-
Gulbis, 2005 {#2877} | HU | 109 | | 1 (0.23/100) | | | | | | Transient hematological toxicity in 1.4/100 pt-yrs
Others
el-Hazmi, 1992 {#154} | HU | 21 | | | | | | | | 6 with leukopenia (WBC<4500/μl )
Charache. 1992 {#2991} | HU | 49 | | | 17 | 1 | | | | No unusual infections; karotypic analysis showed no difference in % abnormal chromosomes pre and post treatment
Voskaridou, 1995 {#2988} | HU | 14 | | | | | | | | Leukopenia or thrombocytopenia in 6; rapidly reversed by holding therapy
Scott, 1996 {#2984} | HU | 15 | | 1 | | | | | 1 | Anemia in 3 of 13 completing study
Olivieri, 1998 {#2979} | HU | 17 | Yes | | 9 | 3 | | | 1
Hanft, 2000 {#197} | HU and no HU (SCD and MPD) | 95 | Yes | | | | | | | HPRT cloning efficiency and VDJ recombination events described in text.
Loukopoulos, 2000 {#2971} | HU | 69 | | | | | | 3 | 0 | 2 with severe anemia; 0/40 with oncogenes; 0/10 with cytogenetic abnormalities
Chaine, 2001 {#2970} | HU | 17 | Yes | | | | | 5 | 13 | Prior leg ulcer associated with ulcer on treatment (p<.005); patients with ulcer were older than those without (p<.001); 3 of 5 resolved with holding HU
Ferguson, 2002 {#2908} | HU ≥ 24 months | 30 | | | | | | | | Stated no adverse events
| HU < 24 months | 30
Schultz, 2003 {#2959} | Patients with SCD and cancer | 49 | Yes | | | | 7 of 16,613; not all on HU | | | 49 cancers in patients with SCD described, in survey of providers
| Patients on HU with cancer | 3 | | | | | 1 | | | Unknown # taking HU, but among 49 patients, 3 were on HU, including 1 with leukemia
Vicari, 2005i {#2957} | HU | 22 | | | 3
Khayat, 2006 {#28} | HU | 8 | Yes | | | | | | | There was no significant difference in mitotic index (p>0.05). There was no significant difference in chromosomal aberrations (p>0.05) pre-and post-treatment

ANC = absolute neutrophil count; HPRT = hypoxanthine phosphoribosyl transferase; HU = hydroxyurea; HUG-KID = pediatric hydroxyurea safety trial; HUSOFT = The Hydroxyurea Safety and Organ Toxicity trial; MPD = myeloproliferative disorders; SCD = Sickle Cell Disease; WBC = white blood cells.

Evidence Table 14. Rarely Reported Adverse Events of Hydroxyurea Treatment for Sickle Cell Disease in Observational Studies

Adverse event | Author, year | # events/# exposed patients
Labyrinthitis | Vicari, 2005i ^80^ | 1/22
Myelotoxicity | Vicari, 2005i ^80^ | 2/22
Dyspepsia | Rigano, 2001 ^71^ | 2/22
| Olivieri, 1998 ^64^ | 1/17
| Yan, 2005 ^188^ | 2/17
Headache | Rigano, 2001 ^71^ | 2/22
| Kinney, 1999 ^68^ | 3/101
| de Montalembert, 1999 ^55^ | 12/84
| Scott, 1996 ^77^ | 2/15
Pancreatitis | Loukopoulos, 2000 ^74^ | 2/69
Need for splenectomy | Loukopoulos, 2000 ^74^ | 2/69
Renal failure | de Montalembert, 1997 ^76^ | 1/35
| Yan, 2005 ^188^ | 1/17 (thought to be unrelated to drug)
Increase in creatinine | Olivieri, 1998 ^64^ | 11/17
Amenorrhea | de Montalembert, 1997 ^76^ | 1/35
ALT elevation | Kinney, 1999 ^68^ | 11/84
Pancytopenia | de Montalembert, 2006 ^48^ | 1/225
Hypersplenism | de Montalembert, 2006 ^48^ | 6/225
Ulcer | Chaine, 2001 ^66^ | 5/17
Conjunctivitis | Olivieri, 1998 ^64^ | 1/17
Hyperbilirubinemia | Zimmerman, 2004 ^81^ | 2/122
Intracranial hemorrhage | Scott, 1996 ^77^ | 1/15

Evidence Table 15. Toxicity Results from Case Reports in Hydroxyurea Treatment of Sickle Cell Disease Only

Outcome | Number of case reports | Females/Males | Mean age at toxicity | Median # of weeks on HU until toxicity | # of case reports with certain causality | # of reports with probable causality | # of reports with possible causality | Level of evidence for this outcome (1, 2, 3)*
Leg ulcer | 1 | 1/0 | 45 | 104 | 0 | 0 | 1 | 3
Leukemia | 3 | 3/0 | 32 | 288 | 0 | 0 | 3 | 3
Cytopenia | 1 | 1/0 | 26 | 153 | 0 | 1 | 0 | 2
Avascular necrosis | 2 | 2/0 | 17 | NR | 0 | 0 | 2 | 3
Splenomegaly | 1 | 1/0 | 32 | NR | 0 | 0 | 1 | 3
Cryptosporidial infection | 1 | 1/0 | 36 | 80 | 0 | 0 | 1 | 3
Intracerebral hemorrhage | 1 | 0/1 | 22 | 52 | 0 | 0 | 1 | 3
Hodgkin's lymphoma | 1 | 0/1 | 8 | 24 | 0 | 0 | 1 | 3
Low sperm count/Motility decrease | 4 | 0/4 | 31 | 128 | 0 | 0 | 4 | 3
Acute myocardial infarction | 1 | 0/1 | 28 | NR | 0 | 0 | 1 | 3
Hyperpigmentation of skin | 2 | 1/1 | 16 | 75 | 0 | 0 | 2 | 3

* WHO causality assessment

HU = hydroxyurea; NR = not reported.

Evidence Table 16. Description of Hydroxyurea Toxicity in Randomized Controlled Trials in Diseases Other than Sickle Cell Disease

Author, year | Location | Recruitment start date - end date | Inclusion and exclusion criteria | Intervention | Starting dose* | Jadad^29^ score
HIV
Frank, 2004^†104^ | North America | Oct 1996–Jan 1998 | Inclusion: Age >18; HIV+; ANC >1000/cmm, platelet >75,000/cmm; Hb >9.2g/dL for men, >8.8g/dL for women, CD4 200–700 | ddI | | 4
| | | Exclusion: Preg; renal failure; liver failure; prior HU; pancreatitis; peripheral neuropathy | HU (low dose) with/without ddI | HU 1000 mg/d
| | | | HU (high dose) with/without ddI | HU 1500 mg/d
Havlir, 2001 ^189^ | North America | Nov 1998 – Jul 1999 | Inclusion: Age >12 years; HIV+; at least 6 months on IDV, ZDV (or d4T), and 3TC); HIV RNA <200/ml; CD4 >200/ul, >100/ul prior to starting IDV | HU IDV ddI d4T | HU 600 BID | 2
| | | Exclusion: ANC <1000/ul; liver failure AST, ALT >3 ULT, documented or suspected hepatitis; prior treatment with HIV protease inhibitor other than IDV or both ddI and d4T; thrombocytopenia <75000/ul; anemia, <8.9 for female and 9.1 g/dl for men; history of grade 2 or greater peripheral neuropathy | IDV ddI d4T + placebo
| | | | IDV ZDV (or d4T) 3TC
Swindells, 2005 ^111^ | North America | Sep 1999–Apr 2007 | Inclusion: Age >12; neutrophil count >1000; HIV-1 RNA between 400–100,000 and CD4 >100; failure of initial anti-retroviral treatment; had not received non-nucleoside reverse transcriptase inhibitors, ABC or ddI; Hb >9 for women >10 for men; plts > 75,000; estimated creatinine clearance >50mL/min, serum lipase <ULN, serum amylase <1.5× ULN, ALT<5× ULN | ABC/EFV/ ddI and HU | HU 500 mg BID | 2
| | | Exclusion: Preg or breast feeding; acute hepatitis within 6 months; immunotherapeutic vaccine or cytotoxic agents within 8 wks before start of study; hx of pancreatitis or peripheral neuropathy within 2 mo before study start | ABC/EFV/ ddI
Beeson, 1999 ^190^ | Europe | Jun 2005 – Jun 2005 | Inclusion: Hb >10g/dL; normal amylase; neutrophil >1500/mcl; included if leucopenia; included if plt >150k/mcl; absence of current HIV-associated disease or prior hx of any AIDS-defining illness | ddI + HU | HU 500 mg BID | 3
| | | | ddI
Bloch, 2006 ^191^ | Australia | Jan 2000 – Feb 2002 | Inclusion: acute primary HIV infection | IDV/RTV/ddI + either stavudine or lamiduvine + HU | HU 500 mg BID | 2
| | | | IDV/RTV/ddI + either stavudine or lamiduvine
Rutschmann Cluster/ HIV
Rutschmann, 1998 ^192^ | Europe | | Inclusion: Age ≥ 20 years; HIV+; CD4 from >200 to <500 (twice); two HIV RNA >1000/ml | ddI/d4T/HU^‡^ | HU 500 mg bid | 3
| | | Exclusion: prior HU; pancreatitis; alcohol; peripheral neuropathy; use of d4T | ddI/stavudine + placebo
Rutschmann, 1998 ^193^ | Europe | | Inclusion: HIV+; CD4 200–500/ul; HIV RNA >1000/ml; staveudine and HU naïve | ddI/stavudine/HU^§^ | HU 500 mg BID | 1
| | | Exclusion: > 6 months of ddI | ddI/stavudine
Rutschmann, 2000^‖194^ | Europe | | Inclusion: CD4 between 2---500; HIV RNA >1000 ×2 | ddI/stavudine/HU | HU 500 mg BID | 2
| | | Exclusion: prior HU; prior stavudine; ddI >6 months | Placebo, ddI stavudine
CML
Hehlmann, 2003 ^113^ | Europe | Feb 1991 – Dec 1994 | Inclusion: newly diagnosed CML in chronic phase | HU | 40mg/kg/d | 2
| | | Exclusion: prior therapy | IFN-alpha 2a + HU | IFN 5*10^6^IU/m2/d + HU added as required
no author, 1998 ^115^ | Europe | Dec 1987–Dec 1992 | Inclusion: Age ≥ 18; previously untreated, newly diagnosed Ph+ CML in chronic phase; BCR-ABL (+); WHO performance status 0,1, or 2; adequate renal/hepatic fxn (bilirubin and creatinine <2× ULN) | HU | NR | 2
| | | Exclusion: cytogenetic abnl other than -y, +8 or second 22q- | IFN and HU if needed | 3 million units 5×/wk
Hehlmann, 1994 ^114^ | Europe | Jul 1983 – Jan 1991 | Inclusion: newly diagnosed, not pretreated CML in chronic phase; fatigue or weight loss or fever or organomegaly-related symptoms or WBC >50,000 or Thrombocytosis >1 million exclusion, Ph(-) or unknown Ph status | HU | 40mg/kg/d | 3
| | | | IFN | 4 million units/m^2^
| | | | Busulfan | 0.1mg/kg/d
Broustet, 1991 ^116^ | Europe | May 1987 – Jul 1990 | Inclusion; Age >18; Ph+ CML | HU | | 3
| | | Exclusion: prior chemo; trisomy 8, isochromosome 17, double Ph+ | IFN | 4 million units/m^2^
Hehlmann, 1993 ^195^ | Europe | Jul 1983 – Jan 1991 | Inclusion: newly diagnosed CML in chronic phase | HU | 40 mg/kg/d | 2
| | | Exclusion: not in chronic phase; no treatment required; prior treatment with IFN or irradiation or cytostatics; lack of consent; second neoplasia; any other reason that made treatment with protocol unlikely | Busulfan | 0.1 mg/kg/d
Solid Tumor
Stephens, 1984 ^121^ | North America | | Inclusion: advanced prostate cancer (stage D disease) | HU | 3600mg/m^2^, 2days/week | 2
| | | Exclusion: unstable ischemic or rheumatic heart disease; heart failure | Adriamycin + cyclophosphamide | Adriamycin at 40 mg/mˆ2 and cyclophosphamide at 200 mg/m^2^; reduced to AC 20+cyclophosphamide 100 if in poor-risk group
Loening, 1981 ^122^ | North America | May 1977 – Apr 1979 | Inclusion: histologically proven prostate CA with distant mets and progression | HU | 3g/m^2^ | 2
| | | | Cyclophosphamide | 1g/m^2^
| | | | Methyl-CCNU | 175mg/m^2^
Najean Cluster/ PV
Najean, 1997 ^123^ | Europe | May 1997–Jun 2005 | Exclusion: age > 65 excluded; previous treatment with radiotherapy; previous treatment with chemotherapy | HU | 25 mg/kg/d | 2
| | | | Pipobroman | 1.25 mg/kg/d
Kiladjian, 2006^¶103^ | | | | HU | | 1
| | | | Pipobroman
ET
Harrison, 2005 ^131^ | Europe | Aug 1997 – Aug 2002 | Inclusion: Age at least 18 yr with ET | HU + aspirin 75mg/d | HU: 0.5–1g/d | 2
| | | | Anagrelide + aspirin 75mg/d | anagrelide 0.5mg BID
Finazzi Cluster/ET
Finazzi, 2000 ^130^ | Europe | 1990-1993 | Inclusion: ET; high risk of thrombosis (>60 yrs or prior thrombosis) | HU | 15mg/kg | 2
| | | | No myelosuppressive agent at randomization^¶^
Cortelazzo, 1995 ^129^ | Europe | Apr 1990 – Aug 1993 | Inclusion: Age >60; previous thrombosis; plt count <1.5 million | HU | 15 mg/kg | 2
| | | | None

* In HIV only HU doses are given

† This was a five-arm study but adverse event data is given for three arms due to pooling of some arms. Treatments naive as well as treatment experienced patients are included. Baseline data is reported for all groups combined (listed in Arm 1) and stated to be similar between arms.

‡ Randomized for 12 weeks then switched to open-label according to patient response in the first 12 weeks.

§ Many patients crossed over after the 12 week-blinding was removed. If they had a poor response (viral load>200/ml) patients were permitted to start HU or dropped if already in HU arm. The HU arm had 34 responders, 24 crossovers after 3 months and 19 remained in the “placebo” arm.

‖ See Rutschmann, 1998^102^ for other details of inclusion criteria, this is the same report after 24 months (instead of 12 months)

¶ This is a follow-up of the previous Najean trial^123^. Very limited data is given on patients.

# Many patients from the placebo group crossed over to HU. 79 received HU alone, 15 received HU and busulfan, and 20 received no chemotherapy.

3TC = Lamivudine; ABC = abacavir; Abnl = abnormal; ALT = alanine aminotransferase; ANC = absolute neutrophil count; AST = aspartate transaminase; BID = twice a day; CA = cancer; CCNU = Lomustine; CML = chronic myelogenous leukemia; d4T = Didehydrodeoxythymidine; ddI = didanosine; EFV = efavirenz; ET = essential thrombocytopenia; Fxn = function; HIV = human immunodeficiency virus; HU = hydroxyurea; hx = history; IDV = indinavir; IFN = interferon; mets = metastases; NR = not reported; Ph = Philadelphia; plt = platelet; preg = pregnancy; PV = polycythemia vera; RNA = ribonucleic acid; RTV=ritonavir; ULN = upper limit of normal; ULT = upper limit; WBC = white blood cells; WHO = World Health Organization; ZDV = zidovudine.

Evidence Table 17. Description of Patient Populations in Randomized Controlled Trials on Hydroxyurea Treatment in Diseases Other than Sickle Cell Disease

Author, year | Intervention groups | N | Age* | Male, n (%) | Race (%) | Last observation
HIV
Frank, 2004^†104^ | ddI | 28 | NR | (79) | White (38); | 6 months
| HU (low dose) with/without ddI | 53 | | | Black (50);
| HU (high dose) with/without ddI | 50 | | | White Hispanic (10 )
Havlir, 2001 ^189^ | IDV, ddI, d4T + HU | 68 | NR | (82) | White (69);
| | | | | Black (16);
| | | | | White Hispanic (13)
| IDV, ddI, d4T + placebo | 68 | | (84) | White (62);
| | | | | Black (22);
| | | | | White Hispanic(12)
| IDV, ZDV(or d4T), 3TC | 66 | | (89) | White (71);
| | | | | Black (23);
| | | | | White Hispanic(5)
Swindells, 2005 ^111^ | ABC, EFV, ddI + HU | 30 | 38.1; Median, 37; [26–59] | 26 (87) | White 16, (53) | 48 wks
| | | | | Black 4, (13);
| | | | | White Hispanic 7, (23);
| | | | | Other 3, (10)
| ABC, EFV, ddI | 24 | 39.5; Median, 37; [29–62] | 21 (88) | White 13, (54);
| | | | | Black 8, (33);
| | | | | White Hispanic 2, (8);
| | | | | Other 1,(4)
Beeson, 1999 ^108^ | ddI +HU | 40 | 33.8; [26–47] | 26 (65) | NR | 40 weeks
| ddI | 21 | 31; [21–48] | 13 (62)
Bloch, 2006 ^191^ | Indinavir, ritonavir, ddI and either stavudine or lamiduvine + HU | 35 | Median, 36; [31–39] | NR | NR
| Indinavir, ritonavir, ddI and either stavudine or lamiduvine | 33 | Median, 34; [29–40]
Rutschmann Cluster/ HIV
Rutschmann, 1998 ^109^ | ddI, stavudine + HU | 72 | NR | NR | NR | 24 wks
| ddI, stavudine + placebo | 72
Rutschmann, 1998 ^102^ | ddI, stavudine + HU | 72 | | | | 48 weeks
| ddI, stavudine + placebo | 72
Rutschmann, 2000^‡110^ | ddI + stavudine + HU | 72 | | | | 24 months
| ddI, stavudine + placebo | 72
CML
Hehlmann, 2003 ^114^ | HU | 308 | Median, 47; [11–83] | (54) | NR
| IFN-alpha 2a + HU | 226 | Median, 49; [10 – 78] | (60)
no author, 1998 ^115^ | HU | 95 | Median, 56.4; [27–84] | 53
| IFN and HU if needed | 100 | Median, 55.7; [20–83] | 58
Hehlmann, 1994 ^113^ | HU | 194 | 46.9; Median, 47; [15–84] | (51)
| IFN | 133 | 47.4; Median, 47; [18–85] | (66)
| Busulfan | 186 | 48.5; Median, 49; [17–84] | (61)
Broustet, 1991 ^116^ | HU | 26 | 58.6 | 16 (61.5)
| IFN | 24 | 55.6 | 15 (62.5)
Hehlmann, 1993 ^112^ | HU | 216 | 49.2 (unclear if mean or median reported) | (52)
| Busulfan | 225 | 50.2 (unclear if mean or median reported) | (61)
Solid Tumor
Stephens,1984 ^121^ | HU | 69 | Median, 64 | (100) | White 55, (77);
| | | | | Black 15, (22);
| | | | | Other 2, (3)
| Adriamycin + cyclophosphamide | 68 | Median, 65 | (100) | White 55, (84);
| | | | | Black 11, (16);
| | | | | Other 2 (3)
Loening, 1981 ^122^ | HU | 40 | 67.3 | (100) | NR | 23 months
| Cyclophosphamide | 43 | 68.8 | (100)
| Methyl-CCNU | 38 | 68.5 | (100)
Najean Cluster/ PV
Najean, 1997 ^123^ | HU | 150 | 53.2, men; 53.6, women | m/f ratio = 0.89 | NR | NR
| Pipobroman | 142 | 55.1, men; 53.3, women | m/f ratio = 1.20
Kiladjian, 2006 ^103^ | HU | 123 | NR | NR | NR
| Pipobroman | 134
ET
Harrison, 2005 ^103^ | aspirin 75mg/d + HU | 404 | Median, 62; [21–88] | 180 (45) | NR
| aspirin 75mg/d + Anagrelide | 405 | Median, 61; [23–88] | 162 (40)
Finazzi Cluster/ET
Finazzi, 2000 ^130^ | HU | 56 | Median, 67; [40–82] | 23.00 | NR
| No myelosuppressive agent at randomization | 58 | Median, 69; [50–85] | 14
Cortelazzo, 1995 ^129^ | HU | 56 | Median, 67 | 23.00 | NR
| None | 58 | Median, 69 | 14

* Mean (SD) [range] unless otherwise specified.

† The characteristics represent the whole population (all three arms).

‡ This study included 30 patients that crossed over to the HU arm (regrouped the arms as received HU at some point vs. no HU), but did not report the numbers of the placebo arm. Denominators for the outcomes range from 64 to 80, because the numbers of patients at the time of the outcome event were used as denominators.

3TC = lamivudine; ABC = abacavir; CCNU = lomustine; CML = chronic myelogenous leukemia; d4T = didehydrodeoxythymidine; ddI = didanosine; EFV = efavirenz; HU = hydroxyurea; IDV = indinavir; IFN = interferon; m/f = male/female; NR = not reported; ZDV = zidovudine.

Evidence Table 18. Toxicity Results in Randomized Controlled Trials on Hydroxyurea Treatment in Diseases Other than Sickle Cell Disease

Author, year | Intervention | N | Mean drug (D) or followup (F) duration | Death, n (%) | Neutropenia, n (%) | Thrombocytopenia, n (%) | Anemia, n (%) | Leukemia, n (%) | Other neoplasm, n (%) | Leg ulcer, n (%) | Skin rash or nail alteration, n (%) | Other n (%)
HIV
Frank, 2004 ^104^ | ddI mono | 28 | D: 6 months | | 3 (11) | 0 | 0 | | | | | Grade 3 chemistry or more, 3 (11)
| HU (low dose) with/without ddI | 53 | | | 10 (19) | 1 (2) | 0 | | | | | Grade 3 chemistry or more, 7 (13)
| HU (high dose) with/without ddI | 50 | | | 20 (40)* | 9 (18)^†^ | 3 (6) | | | | | Grade 3 chemistry or more, 4 (8)
Havlir, 2001 ^189^ | IDV, ddI, d4T, + HU | 68 | F: 40 weeks | 3 | | | | | | | | GI upset, 2
| | | | | | | | | | | | Pancreatitis, 4
| | | | | | | | | | | | Asymptomatic amylase elevation, 2
| IDV, ddI, d4T + placebo | 68 | | 0 | | | | | | | | GI upset, 1
| | | | | | | | | | | | Pancreatitis, 3
| IDV, ZDV (or d4T), 3TC | 66 | | 0
Swindells, 2005 ^111^ | ABC, EFV, ddI + HU | 30 | F: 48 weeks | | | | | | | | 5 | GI upset, 28
| | | | | | | | | | | | Neurological/psychiatric, 23
| | | | | | | | | | | | Endocrine or metabolic, 7
| | | | | | | | | | | | Arthralgia, 2
| | | | | | | | | | | | Fatigue, 6
| | | | | | | | | | | | Neuropathy, 4
| ABC, EFV, ddI | 24 | | | | | | | | | 3 | GI upset, 10
| | | | | | | | | | | | Neurological/psychiatric, 12
| | | | | | | | | | | | Nasal symptoms, 2
| | | | | | | | | | | | Endocrine or metabolic, 3
| | | | | | | | | | | | Arthralgia, 1
| | | | | | | | | | | | Fatigue, 2
| | | | | | | | | | | | Neuropathy, 1
HIV
Seminari, 1999 ^108^ | ddI + HU | 40 | F: 40 weeks | | 1 | 1 | 1 | | | | | Hair loss, 2
| | | | | | | | | | | | hyperamylasemia, 1
| | | | | | | | | | | | hypertryglyceridemia, 1
| ddI | 21 | D: 24 weeks | | 0 | 0 | 0 | | | | | GI upset, 1
| | | | | | | | | | | | Hyperamylasemia, 1
| | | | | | | | | | | | Hypertryglyceridemia, 1
Bloch, 2006 ^191^ | Indinavir, ritonavir, ddI, and either stavudine or lamiduvine + HU | 35 | | | | | 1 | | | | | CMV esophagitis, (3)
| | | | | | | | | | | | renal colic, (20)
| | | | | | | | | | | | pneumonia, (3)
| Indinavir, ritonavir, ddI, and either stavudine or lamiduvine | 33 | | | | | 0 | | | | | Neuropathy, (3)
| | | | | | | | | | | | rectal tear, (3)
| | | | | | | | | | | | renal colic, (3)
Rutschmann Cluster/ HIV
Rutschmann, 1998 ^109^ | ddI, stavudine + HU | 72 | F: 24 weeks | | 14^‡^ | 8^§^ | | | | | 5^‖^ | GI upset, 16
| | | | | | | | | | | | Fatigue, 10
| | | | | | | | | | | | Neuropathy, 18^¶^
| | | | | | | | | | | | Diarrhea, 15
| ddI, stavudine + placebo | 72 | | | 3/ 25 | 3 | | | | | 4 | GI upset, 11
| | | | | | | | | | | | Fatigue, 2
| | | | | | | | | | | | Neuropathy, 10
| | | | | | | | | | | | Diarrhea, 9
Rutschmann, 1998^102#^ | ddI, stavudine + HU | 72 | D: 12–48 weeks | | 11/unclear | 7 | | | | | | Fatigue, 10
| | | F: 48 weeks | | | | | | | | | Diarrhea, 15
| | | | | | | | | | | | Paraesthesia, 29
| ddI, stavudine + placebo | 72 | | | 3** | 1^††^ | | | | | | Fatigue, 2^‡‡^
| | | | | | | | | | | | Diarrhea, 9^§§^
| | | | | | | | | | | | Paraesthesia, 14^‖‖^
Rutschmann, 2000^110#^ | ddI, stavudine + HU | 72 | F: 24 months | | 18^¶¶^ | 29^##^ | | | 4 Kaposis' sarcoma*** | | 8 | GI upset, 20^†††^
| | | | | | | | | | | | Hair loss, 1
| | | | | | | | | | | | Fatigue,16
| | | | | | | | | | | | Neuropathy, 28^‡‡^
| | | | | | | | | | | | Diarrhea, 23
| | | | | | | | | | | | Mucositis, 5
| ddI, stavudine + placebo | 72 | | | 8 | 8 | | | 1 Kaposi's sarcoma | | 5 | GI upset, 6
| | | | | | | | | | | | Hair loss, 1
| | | | | | | | | | | | Fatigue, 5
| | | | | | | | | | | | Neuropathy, 10
| | | | | | | | | | | | Diarrhea, 15
CML
Hehlmann, 2003 ^114^ | HU | 308 | F: 7.3 years | | | | | | | | 29/30 (9.4) | GI upset, 60 (19.5) (denominator= 304)
| | | | | | | | | | | | Flu-like, 38 (12.3)
| | | | | | | | | | | | Neurological/psychiatric, 19 (6.2)
| | | | | | | | | | | | Cardiac/pulmonary symptoms, infections, wt. loss, Lab findings, BM aplasia, 53 (17.2)
| IFN + HU | 226 | Follow-up: 7.9 years | | | | | | | | 64/22 (28.3) | GI upset, 88 (38.9) (denominator=222)
| | | | | | | | | | | | Flu-like, 146 (64.6)
| | | | | | | | | | | | Neurological/psychiatric, 82 (36.3)
| | | | | | | | | | | | Cardiac/pulmonary symptoms, infections, wt. loss, lab findings, BM aplasia, 92 (40.7)
No author, 1998^115^ | HU alone | 95 | F: 51 months | | | | | | | | 1 | Fever, 2
| | | | | | | | | | | | Accelerated disease/blast crisis, 52
| IFN and HU if needed | 100 | | | | | | | | | 3 | Flu-like, 7
| | | | | | | | | | | | Neurological/psychiatric,6
| | | | | | | | | | | | Vasculitis, 1
| | | | | | | | | | | | Accelerated diesease/blast crisis, 37
Hehlmann, 1994 ^113^ | HU | 194 | Median F: 3.4 years | | | | | | 1 (0.5) | | | Fever, 1 (0.5)
| IFN | 133 | | | | | | | 2 (1.5)
| Busulfan | 186 | | | | | | | 2 (1.0)
Broustet, 1991 ^116^ | HU | 26 | D: 20.4 months | | | | 0 | | | | 0
| IFN | 24 | D: 13.9 months | | | | 1 | | | | 1 | Flu-like, 1
| | | | | | | | | | | | CNS disturbance, 2
| | | | | | | | | | | | Thyroid insufficiency, 2
Hehlmann, 1993 ^112^ | HU | 216 | Median F: 2.03 years | | | | | | | | | Long lasting bone marrow aplasia, 0 (denominator=209)
| Busulfan | 225 | | | | | | | | | | Long lasting bone marrow aplasia, unknown (denominator= 204)
Solid Tumor
Stephens, 1984^121^ | HU | 69 | NR | | | 11/68 (16)
| Adriamycin + cyclophosphamide | 68 | NR | | | 9/68 (14)
Loening, 1981^122^ | HU | 40 | NR | | | 2/28 (7) | 8/28 (29) | | | | | GI upset, 13 (46) (denominator=28)
| Cyclophosphamide | 43 | | | | 2/34 (5) | 11/34 (26) | | | | | GI upset, 20 (46) (denominator=43)
| Methyl-CCNU | 38 | | | | 11/27 (41) | 9/27 (33) | | | | | GI upset, 11(41) (denominator=27)
Najean Cluster/ PV
Najean, 1997^123^ | HU | 150 | F: 1 – 17 years | | | | | NR by arm ^§§§^ | 10^‖‖‖^ | 12 (9) | 10 (7) | GI upset, 9 (7)
| | | | | | | | | | | | Myelofibrosis, 26, 40% at the 16th year
| | | | | | | | | | | | Cystitis, 3 (2)
| | | | | | | | | | | | Stomatitis, 13 (10)
| Pipobroman | 142 | | | | | | NR by arm^¶¶¶^ | 6^###^ | 1 | 5 (4) | GI upset, 19 (17)
| | | | | | | | | | | | Myelofibrosis, 3
| | | | | | | | | | | | Stomatitis, 4 (4)
Kiladjian, 2006^103^ | HU | 123^§§§^ | Followup: 14 years | | | | | 15^††††^
| Pipobroman | 134^§§§^ | Followup: 11 years | | | | | 25^‡‡‡‡^
ET
Harrison, 2005 ^131^ | Aspirin + HU | 404 | Median F: 39 months (12–72) | 4^§§§§^ | | | | 6 | | | | Myelofibrosis, 5
| Anagrelide + aspirin | 405 | | 3^‖‖‖‖^ | | | | 4^¶¶¶¶^ | | | | Myelofibrosis, 16^####^
Finazzi Cluster/ ET
Finazzi, 2000^130^ | HU | 56 | Median F: 73 months (3–93) | | | | | | 7 (13)
| No myelosuppressive agent at randomization | 58 | Median F: 73 months (12–94) | | | | | | 1(1.7) *****
Cortelazzo, 1995^129^ | HU | 56 | D: 27 months | | | 0 | | 0 | | | 0
| None | 58 | | | | 0 | | 0 | | | 0

* p = 0.007 (comparing arms 2 and 3)

† p = NS

‡ p = 0.04 for grade 1, ns for 2, 3, (denominator=36)

§ p = 0.03 for grade 1, ns for 2 and 3

‖ p = 0.7

¶ p = 0.09

# n = original assignments, please see associated text for number of patients that crossed over.

** p = 0.04, (denominator for this outcome unclear given crossover)

†† p = 0.03

‡‡ p = 0.02

§§ p = 0.2

‖‖ p = 0.008

¶¶ p = 0.08

## p = 0.001

*** p = 0.2

††† p = 0.006

§§§ Risk = 10% at 13th year (denominator=150)

‖‖‖ Risk = 15% at 14th year, Risk = 1.1% per year

¶¶¶ Risk = 10% at 13th year (denominator =142)

### Risk = 15% at 14th year, Risk = 1.1% per year

**** p = 0.0321 (this symbol doesn't appear in the table)

†††† 6 (40%) occurred after the 12th yr of f/u, (denominator =123)

‡‡‡‡ 11 (44%) after the 12th yr of follow-up (denominator=134)

§§§§ Death from transformation

‖‖‖‖ It is unclear why this only represents 157 patients when it is a follow-up of the original study ^123^. No information on patients lost to follow-up is given

¶¶¶¶ (OR 0.67, CI, 0.20–0.33) p = NS

#### (OR 2.92, CI, 1.24 – 6.86) p = 0.01

***** p = 0.0321

3TC = lamivudine; ABC = abacavir; ARV = antiretroviral; BM = bone marrow; CCNU = lomustine; CI = confidence interval; CMV = cytomegalovirus; CNS = central nervous system; d4T= didehydrodeoxythymidine; ddI = didanosine; EFV = efavirenz; ET = essential thrombocytopenia; GI = gastrointestinal; HU = hydroxyurea; IDV = indinavir; IFN = interferon; NR = not reported; NS = not significant; OR = odds ratio; PV = polycythemia vera; wt = weight; ZDV = zidovudine.

Evidence Table 19. Description of Large Observational Toxicity Studies of Hydroxyurea Treatment in Diseases Other than Sickle Cell Disease

Author, year | Location | Design | Disease | Recruitment start date - end date | Inclusion & exclusion criteria | Intervention | Starting dose: Titration Dose | Planned duration/last observation | Total Q score
CML/AML
Yin, 2006 ^117^ | North America | Case series | CML | Jan 1997 – Sep 2004 | Inclusion: t (3;21) translocation | 15 -HU, 1 -imatinib | | 2 weeks to 31 months/ last observation, median 3 months | 65
| | | AML | | | 8 varieties of prior chemo: two patients had no prior therapy
Urabe, 1990 ^119^ | Asia | Case series | CML | May 1988 - NA | Inclusion: CML | HU | NR | Last observation mean, 20.1 months* | 30
Vassallo, 2001 ^118^ | Europe | Case series | CML | 1977 - 1998 | Exclusion: diabetes; peripheral venous insufficiency; condylomata acuminata; cancer/precancerous lesions; exposure to carcinogens/radiation; previously treated with anything but HU; rheumatological and autoimmune disorders | HU | 1500–2000 mg/d; reported maintenance doses of 500 to 1000 mg/d based on response | | 54
Duletic-Nacinovic, 2000 ^120^ | Europe | Cohort with comparison arm | CML | Jan 1986 – Jun 1997 | Inclusion: CML 1st chronic phase | HU | 40 mg/kg/d: dose decreased to 20 mg/kg when WBC decreased to 20,000 | | 63
| | | | | | Busulfan | 0.1 mg/kg/d: dose decreased by 50% when WBC decreased by 50%, discontinued when WBC dropped below 20,000
PV/ET/MF/unspecified MPD
Nielsen, 2003 ^134^ | Europe | Cohort with comparison arm | PV, ET, IMF unclassified MPD^†^ | Jan1993 – Dec 2000 | Inclusion: chronic MPD, Philadelphia chromosome negative | HU | 650.1 g HU (range 1–3,200 g) | | 64
| | | | | | No drug treatment
| | | | | | Busulfan alone
| | | | | | Busulfan + HU
| | | | | | Anagrelide + HU
| | | | | | Busulfan, IFN + HU
| | | | | | Busulfan, Anagrelide + HU
| | | | | | IFN + HU
Weinfeld, 1994 ^135^ | NR | Other prospective cohort | PV, ET, IMF | 1976 - NR | Inclusion: myeloproliferative disorders | PV/HU | 30 mg/kg/d: day 8 reduced by 50% and adjusted to blood counts maintenance dose of 0.5 to 1.5 g/d) | NR | 23
| | | | 1976 - NR | | ET/HU | 30 mg/kg/d: day 8 reduced by 50% and day 8 reduced by 50% and adjusted to blood counts (maintenance dose of .5 to 1.5 g/d)
| | | | 1976 - NR | | MF/HU | 30 mg/kg/d: day 8 reduced by 50% and day 8 reduced by 50% and adjusted to blood counts (maintenance dose of .5 to 1.5 g/d)
Randi, 2005^‡136^ | Europe | Case series | PV, ET | | Inclusion: Age >60; PV or ET diagnosed by PVSG criteria; previous thrombotic event (n=72); plt count >1,500K/ml | HU | 30 mg/kg per day | 4.33 years | 46
Randi, 2005^137^ | Europe | Case series | PV, ET | | Inclusion: Age >60 years; previous major thrombotic event; platelet count over 1500×10^9^/L | HU | 30mg/kg/day: maintenance dose 15mg/kg/day | Patients observed over a period of 20 years | 31
Mavrogianni, 2002 ^196^ | Europe | Cohort with a comparison arm | PV, ET | NR | NR | PV: HU therapy | NR | 86 ( range, 36–195) months | 57
| | | | | | ET: HU therapy
| | | | | | PV: busulfan
| | | | | | ET: alpha IFN
PV
Finazzi, 2005 ^124^ | Europe | Case series | PV | 1997 - 2001 | Inclusion: diagnosis of PV by PVSG | HU | | | 63
| | | | | | Any other cytoreductive drug
| | | | | | No drug or alpha IFN only
West, 1987 ^128^ | North America | Case series | PV | 1963 - 1983 | Inclusion: PV | HU | 500 mg: based on blood counts, mean daily dose of 720mg | 64.9 months | 33
Donovan, 1984 ^127^ | North America | Case series | PV | | Inclusion: PV; off all therapy for four months prior to starting HU | HU no prior treatment | 30 mg/kg day × 1 week then 15 mg/kg: 5/mg/kg/d changes to keep HCT controlled | | 53
| | | | | | HU and prior myelosuppressive therapy | 30 mg/kg day × 1 week then 15 mg/kg: 5/mg/kg/d changes to keep HCT controlled
Najean, 1996 ^105^ | Europe | Cohort with a comparison arm | PV | | | HU | 30mg/kg/d (initial dose) 8mg/kg/d (maintenance dose) | | 28
| | | | | | Pipobroman | 1.5mg/kg/d (initial dose) 0.4 mg/kg/d (maintenance dose)
| | | | | | ^32^P +HU | NR
| | | | | | ^32^P without maintenance | NR
Wasserman Cluster/PV
Kaplan, 1986 ^125^ | North America | Cohort with a comparison arm^§^ | PV | | Exclusion: previously treated with myelosuppresive agents | HU | | 61 (245 weeks) | 44
| | | | | | Phlebotomy
Fruchtman, 1997^126^ | North America | Cohort with a comparison arm | PV | | Inclusion: PV | HU | | Last observation: 198.75 months | 60
| | | | | Exclusion: prior chemo | Phlebotomy
ET
Chim, 2005 ^133^ | Southeast Asia | Case series | ET | | Inclusion: Essential Thrombocytosis | HU alone | | | 67
| | | | | | Melphalan + HU
| | | | | | ^32^P + HU
Bernasconi, 2002 ^107^ | Europe | Case series | ET | 1985 - 1995 | | HU alone | 15 mg/kg/d | | 67
| | | | | | Pipobroman | 1 mg/kg/d
| | | | | | None
Gangat, 2007 ^106^ | North America | Cohort with a comparison arm | ET | Jul 1956 – Dec 2005 | | HU | | median follow-up for the entire study population: 84 months (range, 0–424) | 73
| | | | | | Anagrelide or IFN only
| | | | | | Exposure to single agent cytotoxics other than HU
| | | | | | No drug exposure
| | | | | | Anagrelide or IFN-alpha + HU
| | | | | | Other cytotoxics (busulfan, chlorambucil, ^32^P) + HU
Sterkers, 1998^132^ | Europe | Case series | ET | 1970 – Jan 1991 | Inclusion: ET | HU alone | 1.5 g/d | Fourteen patients had received HU, during a median period of 53 months (range, 3 to 96); seven of them had received HU alone, and seven had also received other treatments
| | | | | | HU with other agents
| | | | | | ^32^P alone | 0.1 mCi/kg
| | | | | | ^32^P with other agents
| | | | | | Busulfan alone | 6 mg/d
| | | | | | Busulfan with other agents
| | | | | | Pipobroman alone | 1 mg/kg/day
| | | | | | Pipobroman with other agents
| | | | | | No treatment

* No data was given on the average time each patient was treated, and no info on demographics was reported.

† No demographic information reported based on chemo. Data only given only by disease type.

‡ Four patients with short-time toxicity; 12 patients with long-term side effects needing drug withdrawal; 65 patients with minor side-effects (black nail pigmentation; asymptomatic macrocytosis).

§ Compared two population groups from different studies.

32 P = radioactive phosphorus; AML = acute myelogenous leukemia; CML = chronic myelogenous leukemia; ET = Essential thrombocytopenia; HCT = hematocrit; HU = hydroxyurea; IFN = interferon; IMF = idiopathic myelofibrosis; MF = Myelofibrosis; MPD = myeloproliferative disorder; NA = not applicable; NR = not reported; plt = platelets; Pts = patients; PV = Polycythemia vera; PVSG = Polycythemia Vera Study Group; Q = quality; WBC = white blood cells.

Evidence Table 20. Description of Patient Populations in Large Observational Toxicity Studies of Hydroxyurea in Diseases Other than Sickle Cell Disease

Author, year | Patient groups: intervention | N | Age, mean (SD) [range]* | Male n (%) | Race (%)
CML/AML
Yin, 2006 ^117†^ | 15 -HU, 1 -imatinib | 16 | Median, 53; [21–76] | 13 | NR
| 8 varieties prior chemo: two patients had no prior therapy | 10 | Median, 65; [53–76] | 3
Urabe, 1990 ^119^ | HU | 134 | NR | NR | NR
Vassallo, 2001 ^118^ | HU | 158 | Median, 58; [25–79] | m/f ratio=3.5:1 | NR
Duletic-Nacinovic, 2000 ^120^ | HU | 72 | Median, 42.69; [10–81] | (52.8) | NR
| Busulfan | 109 | Median, 47.54; [7–84] | (59.6)
PV/ET/MF/unclassified MPD
Nielsen, 2003 ^134^ | HU | 36 | 64.4 for arms 1,4,5,6,7,8 | 22 (38) for arms 1,3,4 | NR
| No drug treatment | 21 | 62.3 for arms 2,3
| Busulfan alone | 4 | NR
| Busulfan + HU | 18 | NR
| Anagrelide + HU | 1 | NR
| Busulfan, IFN + HU, | 1 | NR | 17 (68)
| Busulfan, Anagrelide, + HU | 1 | NR | NR
| IFN + HU | 1 | NR | NR
Weinfeld, 1994 ^135^ | PV: HU | 30 | 61 | NR | NR
| ET: HU | 10 | 60
| MF: HU | 10 | 66
Randi, 2005 ^136^ | HU | 152 | 58.12 ± 14.68 (at diagnosis) | 62
Randi, 2005 ^137^ | HU | 129 | NR | 53
Mavrogianni, 2002 ^196^ | PV: HU therapy | 34 | 62 [38–80] | 15 out of 35 PV patients | NR
| ET: HU therapy | 30 | 64 [18–83] | 20 out of 34 ET patients
| PV: HU/busulfan | 1 | NR | NR
| ET: IFN alpha | 4 | NR | NR
PV
Finazzi, 2005 ^124^ | HU | 742 | Median, 67.3 | NR | NR
| Any other cytoreductive drug | 227 | NR
| Either no drug, or IFN alpha only | 669 | NR
West, 1987 ^128^ | HU | 100 | 54.6; [24–88] | 78 | White 99; Black 1
Donovan, 1984 ^127^ | HU no prior treatment | 59 | NR | (56) | NR
| HU and prior myelosuppressive therapy | 59 | | (51)
Najean, 1996 ^105^ | HU | 104 | Median, 58 (combined with Arm2) | NR | NR
| Pipobroman | 98 | Median, 58 (combined with Arm1)
| ^32^P+HU | 174 | 74 (at diagnosis, combined with Arm 4)
| ^32^P without maintenance | 221 | 74 (at diagnosis, combined with Arm 3)
Wasserman Cluster/PV
Kaplan, 1986 ^125^ | HU | 51 | NR | (53) | NR
| Phlebotomy | 134 | | (55)
Fruchtman, 1997 ^126^ | HU | 51 | NR | (53) | NR
| Phlebotomy | 134 | | (55)
ET
Chim, 2005 ^133^ | HU alone | 222 | Median, 65; [18–90] | (49) | Asian/Pacific Islander, (100)
| Melphalan + HU | 3
| ^32^P + HU | 4
Bernasconi, 2002 ^107^ | HU | 23 | Median, 55; [15–86]^‡^ | 68: out of 155 ^‡^ | NR
| Pipobroman | 106
| None | 26
Gangat, 2007 ^106^ | HU only | 165 | Median, 57; [5–96]^‡^ | 206: out of 605^‡^ | NR
| Anegralide or IFN only | 63
| Exposure to single agent cytotoxics other than HU | 21
| No drug exposure | 181
| Anagrelide or IFN alpha + HU | 128
| Other cytotoxics + HU | 47
Sterkers, 1998^132^ | HU alone | 201 | NR | NR | NR
| Other agents + HU | 50
| ^32^P alone | 29
| Other agents + ^32^P | 11
| Busulfan alone | 35
| Other agents + busulfan | 6
| Pipobroman alone | 12
| Other agents + pipobroman | 31
| No treatment | 31

* Unless otherwise specified

† Median 3 months for last observation

‡ These are the characteristics of entire cohort, no subgroup data were reported.

32 P= radioactive phosphorus; ACL = acute myelogenous leukemia; CML = chronic myelogenous leukemia; ET = Essential thrombocytopenia; HU = hydroxyurea; IFN = interferon; m/f = male to female ratio; MF = Myelofibrosis; MPD = myeloproliferative disorder; NR= not reported; PV= Polycythemia vera; SD = standard deviation.

Evidence Table 21. Toxicity Results of Observational Studies of Hydroxyurea in Diseases Other than Sickle Cell Disease*

Author, year | Intervention | N | Mean duration of drug (D) or followup (F) in months^†^ | Death, n (%) | Neutropenia, n (%) | Thrombocytopenia, n (%) | Anemia, n (%) | Leukemia, n (%) | Other neoplasm, n (%) | Leg ulcer, n (%) | Skin rash/nail alteration, n (%) | Other, n (%)
CML/AML
Yin, 2006 ^117^ | 15 -HU 1 -imatinib | 16 | D: HU, 2 weeks-31 months before translocation; | 8/15
| | | D: imatinib alone, 3 months
| 8 varieties prior chemo: two patients had no prior therapy | 10 | | 7/9
Urabe, 1990 ^119^ | HU | 134 | NR | | | | | | | | 1 | Liver dysfunction, 1
| | | | | | | | | | | | GI upset, 1
Vassallo, 2001 ^118^ | HU | 158 | D: Median = 38 months | | | | | | 5 | | 21^‡^
Duletic-Nacinovic, 2000 ^120^ | HU | 72 | F: Median = 32 months | | 2 | | 0 | | | | 0
| Busulfan | 109 | F: Median = 31 months | | 8 | | 2 | | | | 2 | Lung fibrosis, 3
| | | | | | | | | | | | Amenorrhea, 2
PV/ET/IMF/unspecified MPD
Nielsen, 2003 ^134^ | HU | 36 | F: 7.8 years (follow-up for all patients that received HU) | | | | | 5
| No drug treatment | 21 | F: 10.5 years (this is follow-up for all patients that did not receive HU) | | | | | 1
| Busulfan alone | 4 | | | | | | 0
| Busulfan + HU | 18 | | | | | | 4
| Anagrelide + HU | 1 | | | | | | 0
| Busulfan, IFN + HU | 1 | 62 | | | | | 1
| Busulfan, anagrelide + HU | 1 | 84 | | | | | 1
| IFN + HU | 1 | 21 | | | | | 1
Weinfeld, 1994 ^135^ | PV: HU | 30 | NR | | | (30) | | 3 | | | | Chromosomal anomalies, 4/11; platelet count >6×10^9^/l
| ET: HU | 10 | | | | (30) | | 1 | | | | Chromosomal anomalies, 1/5; platelet count >6×10^9^/l
| MF: HU | 10 | | | | | | 3 | | | | Chromosomal anomalies, 2/3
Randi, 2005^§136^ | HU | 152 | Median 4.33 years aspirin (n=88), ticlopicine (n=11), oral anticoagulants (n=12), 8.13 years | 3 (1.97) | | | 5 (0.0329) | 3, (1.97) | | 4 (2.6) | | Cutaneous allergic reaction and mild pancytopenia, 1; Allergic reaction and transient liver failure, 1; Fever above 39°C, 2
Randi, 2005 ^137^ | HU | 129 | F: 7.18 years | | | | 2/129 | 3 | 1 | 4 | 3 | CV complications, 4
| | | | | | | | | | | | Coronary complications, 5
| | | | | | | | | | | | Fever above 39°C, 2
Mavrogianni, 2002 ^196^ | PV: HU therapy | 34 | D: 86 [36–195] months | | | | | 2 (5.7)
| ET: HU therapy | 30 | D: 79 [36–162] months | | | | | 1 (3.3)
| PV: HU and busulfan | 1 | D: 44 months on HU followed by 86 months on busulfan | | | | | | | | 1
| ET: INF α | 4 | D: 105 [91–123] months
PV
Finazzi, 2005 ^124^ | HU only | 742 | | | | | | 6
| Any other cytoreductive drug | 227 | | | | | | 11
| No drug or interferon α only | 669 | | | | | | 5
West, 1987 ^128^ | HU only | 100 | D: 3–216 months, mean 64.9 [3–21] | | | | | 2 (2) | 1 (1) | | 1 | Splenic infarction, 1
| | | F: 20 year observation | | | | | | | | | Myelofibrosis, 6
Donovan, 1984 ^127^ | HU no prior treatment | 59 | F: 61 weeks to 171 weeks | | | | | 2
| HU after prior myelosuppressive therapy | 59 | F: 193 weeks | | | | | 1
Najean, 1996 ^105^ | HU only^§^ | 104 | Median followup: 6.7 years | | | | | 13% at 12y f/u^‖^ | 9% at 10y f/u^¶^ | | | Myelofibrosis, 17% at 12 year f/u
| pipobroman | 98 | Median followup: 6.7 years | | | | | 14% at 12y f/u^‖^ | 9% at 10y f/u^¶^
| ^32^P+HU maintenance | 174 | D: 1–15 years | | | | | 19% at 10y f/u^#^ | 29% at 12y f/u^‖^ | | | Myelofibrosis, 16% at 10 year f/u; 23% at 14 year f/u
| | | Median 10.5 years
| ^32^P without maintenance | 221 | D: 1–15 years, | | | | | 10% at 10y f/u | 15% at 12y f/u^‖ **^ | | | Myelofibrosis, 10% at 10 year f/u; 19 at 14 year f/u
| | | Median 10.5 years
Wasserman Cluster/PV
Kaplan, 1986 ^125^ | HU | 51 | D: Median 245 weeks (range: 5–389 weeks) | | | | | 3 (5.9)
| Phlebotomy | 134 | NR | | | | | 2 (1.5) ^††^
Fruchtman, 1997 ^126^ | HU | 51 | F: 795 weeks | 16 (31.4) ^‡‡^ | | | | 5 (9.8) ^§§^ | | | | Spent phase, 4
| Phlebotomy | 134 | NR | 54 (40.3) | | | | 5 (3.7) | | | | Spent phase, 15
ET
Chim, 2005 ^133^ | HU alone | 224 | F: 10 years | | | | | 3 (1.3) | | | | Myelofibrosis, 6
| Melphalan + HU | 4 | | | | | | 2 | | | | Myelofibrosis, 1
| Phosphorus + HU | 3 | | | | | | 0
Bernasconi, 2002 ^107^ | HU only | 23 | Median F: 104 months (range, 8–240) for all three groups | | | | | 4^‖‖^
| Pipobroman | 106 | | | | | | 4^¶¶^
| No treatment | 26 | | | | | | 0
Gangat, 2007 ^106^ | HU only | 165 | Median F: 84 months (0–424) | | | | | 5
| Anegralide or IFN α only | 63 | | | | | | 1
| Exposure to single agent cytotoxics other than HU | 21 | | | | | | 3
| No drug exposure | 181 | | | | | | 4
| Anagrelide or IFN + HU | 128 | | | | | | 2
| Other cytotoxics + HU | 47 | | | | | | 5
Sterkers, 1998 ^132^ | HU alone | 201 | Median F: 98 months ( 22 – 265) | | | | | 7 (3.5)
| HU + other agents | 50 | | | | | | 7 (14)
| ^32^P alone | 29 | | | | | | 2 (7)
| ^32^P + other agents | 11 | | | | | | 1 (9)
| Busulfan alone | 35 | | | | | | 1 (3)
| Busulfan + other agents | 6 | | | | | | 1 (17)
| Pipobroman alone | 12 | | | | | | 0
| Pipobroman + other agents | 31 | | | | | | 5 (16)
| No treatment | 31 | | | | | | 0

* Denominators = N unless otherwise specified.

† Unless otherwise specified

‡ HU therapy was discontinued in all 21 patients showing toxicity, and all cutaneous ulcers healed within a median period of 9 months.

§ 12 patients originally assigned to the HU arm were switched to pipobroman, and 5 patients on the pipobroman arm were switched to the HU arm.

‖ Actuarial risk

¶ Observed risk

# Reported as “significant” when compared to no maintenance arm

** p < 0.01 at 10 year f/u compared to Arm 3

†† p > 0.25

‡‡ p = 0.0718

§§ p = 0.0973

‖‖ Incidence rate ratio HU v PI 6.15, CI, 1.4–26.99, 5-year CI = 8.09%, 10-year CI = 15.53%, 15-year CI = 22.37% (where CuI is cumulative incidence, p for IRR = 0.0198

¶¶ 5-year CuI = 1.97%, 10-year CuI = 3.89%, 15-year CuI = 5.78%

32 P = radioactive phosphorus; CV = Cardiovascular; ET = Essential thrombocytopenia; f/u = followup; GI = Gastrointestinal; HU = Hydroxyurea; IFN = Interferon; MF = Myelofibrosis; MPD = Myeloproliferative Disorder; NR = Not reported; PV = Polycythemia vera.

Evidence Table 22. Adequacy of Reporting in Controlled Trials on Hydroxyurea Treatment in Diseases Other the Sickle Cell Disease*

Author/year | Source population | Inclusion criteria | Baseline characteristics | Intervention | Adherence | Quality score
Frank, 2004 ^104^
Havlir, 2001 ^189^ | 1 | | 0 | | 1 | 2
Swindells, 2005 ^111^ | 1 | | 0 | | 1 | 2
Beeson, 1999 ^108^
Bloch, 2006 ^191^
Rutschmann, 1998 ^109^
Rutschmann, 1998 ^102^ | 1 | | 0 | | 0 | 1
Rutschmann, 2000^‖110^ | 1 | | 0 | | 1 | 2
Hehlmann, 2003 ^114^
The Benelux CML Study Group, 1998 ^115^ | 1 | | 0 | | 1 | 2
Hehlmann, 1994 ^113^ | 1 | 1 | 0 | | 1 | 3
Broustet, 1991 ^116^ | 1 | 1 | 0 | | 1 | 3
Hehlmann, 1993 ^112^ | 1 | | 0 | | 1 | 2
Stephens, 1984 ^121^ | 1 | | 0 | | 1 | 2
Loening, 1981 ^122^
Najean, 1997 ^123^ | 1 | | 0 | | 1 | 2
Kiladjian, 2006 ^103^
Harrison, 2005 ^103^
Finazzi, 2000 ^130^ | 1 | | 0 | | 1 | 2
Cortelazzo, 1995 ^129^ | 1 | | 0 | | 1 | 2

* Blank cells represent categories that were not applicable to the question

Evidence Table 23. Adequacy of Reporting in Observational Studies of Hydroxyurea Treatment in Diseases Other than Sickle Cell Disease*

Author/year | Source population | Inclusion criteria | Baseline characteristics | Intervention | Adherence | Adjustment for outcome comparison reporting | Objective outcome | Losses to follow-up | Overall assessment (% of total)
Yin, 2006 ^117^ | 1.5 | 1 | 1.5 | | | | 2 | | 65
Urabe, 1990 ^119^ | 1.5 | 0 | 0 | 1 | 0 | | 2 | 0 | 30
Vassallo, 2001 ^118^ | 2 | 1 | 0.5 | 1.5 | 0 | | 2 | | 54
Duletic-Nacinovic, 2000 ^120^ | 2 | 0.5 | 2 | 2 | 0 | 0.5 | 2 | 1 | 63
Nielsen, 2003 ^134^ | 2 | 2 | 1.5 | 1 | 0 | 0.5 | 2 | | 64
Weinfeld, 94 ^135^ | 1 | 0 | 0.5 | | 0 | | 1 | 0 | 23
Randi, 2005^‡136^ | 1 | 1 | 1 | 1.5 | 0 | | 1.5 | | 46
Randi, 2005 ^137^ | 0.5 | 0.5 | 1 | | 0 | | 1.5 | 0 | 31
Mavrogianni, 2002 ^196^ | 1 | 2 | 2 | 1 | 0 | | 2 | 0 | 57
Finazzi, 2005 ^124^ | 1.5 | 1.5 | 1.5 | 1 | 0 | 2 | 2 | | 63
West, 87 ^128^ | 1 | 0.5 | 1 | 1 | 0 | | 1.5 | 0 | 33
Donovan, 1984 ^127^ | 1.5 | 1.5 | 1.5 | 1.5 | 0 | | 2 | 0 | 53
Najean, 96 ^105^ | 0.5 | 0.5 | 0.5 | 1 | 0 | 0 | 1 | 1 | 28
Kaplan, 86 ^125^ | 1 | 0.5 | 1 | 0.5 | 0.5 | 1.5 | 1.5 | | 53
Fruchtman, 1997 ^126^ | 1.5 | 1.5 | 2 | 2 | 0 | 0 | 2 | | 60
Chim, 2005 ^133^ | 1.5 | 1.5 | 2 | 1 | 0 | 2 | 2 | | 67
Bernasconi, 2002 ^107^ | 2 | 2 | 1.5 | 2 | 1 | | 1.5 | 0 | 67
Gangat, 2007 ^106^ | 2 | 2 | 2 | 1 | 0 | 2 | 2 | | 73
Sterkers 1999 ^132^ | 1 | 2 | 1 | 2 | 0 | 1 | 2 | | 64

* Blank cells represent categories that were not applicable to the question.

Evidence Table 24. Hydroxyurea Toxicity Results from Case Reports in Disease Other than Sickle Cell Disease

Outcome | # of case reports | Females/males | Underlying disease % | Median weeks on HU until toxicity | # of case reports with certain causality | # of reports with probable causality | # of reports with possible causality | # of reports with unlikely causality | Evidence level for outcome* (1, 2, 3)
Alopecia | 1 | 1/0 | CML 100 | 16 | | | 1 | | 3
Alveolitis | 2 | 0/2 | CML 50; | 4 | | 1 | 1 | | 2
| | | MPD 50
Arthritis | 1 | 0/1 | CML 100 | 12 | | | 1 | | 3
Azosperm or decreased sperm motility | 2 | 0/2 | ET 50; | 470 | 1 | | 1 | | 1
| | | PV 50
Behcet's disease | 2 | 2/0 | CML 100 | 91 | | | 1 | 1 | 3
Colitis | 1 | 0/1 | CML 100 | 2 | | 1 | | | 2
Cytopenia | 2 | 0/2 | HIV 100 | 12 | | 1 | 1 | | 2
Eyelid changes | 1 | 0/1 | CML 100 | NR | | 1 | | | 2
Falsely elevated HbA1c | 1 | 0/1 | PV 100 | NR | | | | 1 | 0
Fever | 15 | 6/9 | ET 73; | 3 | 14 | | 1 | | 1
| | | CML 13;
| | | other 16
Gangrene of toes | 2 | 1/1 | CML 100 | 175 | | | 2 | | 3
Glioblastoma multiforme | 1 | 1/0 | MPD 100 | 150 | | | 1 | | 3
Hemolytic anemia | 1 | 0/1 | ET 100 | 150 | | 1 | | | 2
Hepatitis | 6 | 2/4 | ET 33; | 27 | 3 | 1 | 2 | | 1
| | | PV 33;
| | | Psoriasis 33
Interstitial Pneumonitis | 5 | 1/4 | CML 40; | 16 | 1 | 3 | 1 | | 1
| | | ET 40;
| | | MPD 20
Leg ulcer | 66 | 27/39 | CML 48; | 220 | 4 | 31 | 31 | | 1
| | | ET 20;
| | | PV 27;
| | | MPD 4
Leukemia | 33 | 15/18 | ET 57; | 300 | | | 30 | 3 | 3
| | | PV 24;
| | | MPD 6;
| | | Hypereosinophilia 6
Limbal stem cell deficiency (cornea) | 1 | 0/1 | CML 100 | 104 | 1 | | | | 1
Lymphoma | 2 | 1/1 | ET 50; | 450 | | | 2 | | 3
| | | Hypereosinophilia 50
Melanoma | 1 | 0/1 | ET 100 | 64 | | | 1 | | 3
Meningioma | 1 | 1/0 | ET 100 | 520 | | | 1 | | 3
Multiple myeloma | 1 | 1/0 | ET 100 | 360 | | | 1 | | 3
Nail change | 9 | 8/1 | CML 55; | 104 | | 2 | 7 | | 2
| | | ET 33;
| | | Psoriasis 11
Neuromuscular disorder | 1 | 0/1 | CML 100 | 4 | | | 1 | | 3
Oral ulcers | 4 | 0/4 | ET25; Leukemia 75 | 116 | | 2 | 2 | | 2
Pruritis | 1 | 1/0 | PV 100 | 5 | 1 | | | | 1
Pulmonary Fibrosis | 1 | 1/0 | PV 100 | 16 | | | 1 | | 3
Dermatological changes | 34 | 19/15 | CML 68; | 222 | | 19 | 15 | | 2
| | | ET 6;
| | | PV 26;
| | | Leukemia 3
Sarcoidosis | 1 | 0/1 | ET 100 | 16 | | | 1 | | 3
Sarcoma | 1 | 0/1 | ET 100 | | | | 1 | | 3
Skin cancer | 27 | 9/18 | CML 41; | 376 | 1 | 6 | 20 | | 1
| | | ET 29;
| | | PV 29
SLE | 1 | 1/0 | Psoriasis 100 | 160 | | 1 | | | 2
Soft-tissue Nodule | 1 | 0/1 | MPD 100 | 32 | | 1 | | | 2
Thrombotic microangiopathy | 1 | 1/0 | CML 100 | 72 | | | 1 | | 3
Tumor lysis | 4 | 1/3 | CML 25; | 0.56 | | | 4 | | 3
| | | Leukemia 50;
| | | PV 25
Ulcer (surgical site) | 1 | 1/0 | PV 100 | 300 | | 1 | | | 2

* Level 1 evidence had to have at least 1 “certain” case report, level 2 evidence had to have at least 1 “probable” but no “certain” report, and level 3 evidence had to have at least 1 “possible” report but no “certain” or “probable” case report.

CML= chronic myelogenous leukemia; ET=essential thrombocytopenia; HIV = human immunodeficiency virus HU=hydroxyurea; MPD= myeloproliferative disorders; NR=not reported; PV= polycythemia vera; SLE= Systemic lupus erythematosus.

Evidence Table 25. Barriers and Facilitators (Patient, Provider, and Societal) Shown to be Associated with Treatment for Patients with Sickle Cell Disease

Author, year | Outcome | Study population | N | Barriers | Facilitators | Neither | Primary results
| Measurement | Location
Studies Concerning Barriers to Receipt of Treatment to Increase Hemoglobin F
Hankins, 2007 ^138^ | Patient decision to initiate HU | Patients (Children, caregivers)/ | 30 | | Perceived safety and efficacy | Parental age, sex, # of children, parent's rating of child's HRQOL, frequency of VOC in prior 2 years | In this study of patient and parental treatment decisions, after hearing non-biased information about all three potential treatments, the majority of patients and parents (70%) chose HU therapy over chronic transfusion (17%) and stem cell transplantation (10%) (p < 0.001). The perceived efficacy and perceived safety of potential treatment options were the two most commonly cited factors affecting parental treatment preferences for their kids (~80% of respondents each). Health related quality of life (HRQOL) and number of vaso-occlusive crisis events were not associated with treatment preference. There was disagreement over treatment preference in 3 out of 7 patient-parent dyads.
| Patient report, family report | Memphis, TN
Studies Concerning Barriers to Patient Adherence to Established Therapies for Disease Management
Treadwell, 2005 ^139^ | Patient adherence to chelation therapy | Patients (Children, Caregivers) | 15 | Family stress | Child-parent shares responsibility | Convenience of the regimen, behavioral/psychological adjustment, patient/caregiver knowledge, satisfaction with regimen, child cognitive disability | The developmentally appropriate sharing of responsibilities for chelation therapy between parents and their children with SCD contributes to better adherence to home deferoxamine administration (p<0.05). Low family stress was marginally related to better adherence (p = 0.07). There was no difference between the most and least adherent group in the perception of the inconvenience of the deferoxamine regimen (significance not shown). The child's behavioral and psychological adjustment was not associated with adherence (significance not shown). The primary hypothesis, that greater child cognitive disability would be a risk factor for non-adherence, was not supported by the data (significance not shown).
| Patient or caregiver report, physical examination, administrative records | California
Wurst, 2004 ^140^ | Provider provision of prophylactic antibiotics/ | Physicians (hematologists, heme/ onc, pediatricians)/ | 142 | Academic medical center setting | Provider knowledge, provider specialty | Provider years in practice, provider gender | Pediatricians were more likely than hematologists to answer correctly 5 or 6 out of 6 questions on SCD antibiotics guidelines (p<0.001). Pediatricians were significantly more likely than hematologists to be 100% adherent in prescribing antibiotics prophylaxis (p=0.001). Physician knowledge of antibiotic prophylaxis prescribing guidelines was associated with better physician adherence to prescribing antibiotics (p=0.031). Physicians in a medical school or university setting were significantly less likely than physicians in other settings to be 100% adherent (p=0.033).
| Provider report | North Carolina
Sox, 2003^141^ | Receipt of prophylactic antibiotics | Patients (Children/Caregivers) | 261 | NR | Private insurance, hospital visits | Patient sex, patient age, urban residence, cost-sharing, non-preventive outpatient care visits | Publicly insured children may receive an inadequate amount of prophylactic antibiotics against pneumococcal infections, as the children in this sample were dispensed an average of only 148.4 days of coverage out of a 365 day period (SD: 121.4, median:114, IQR 39 – 247). The number of outpatient visits for preventive care and the number of emergency department visits experienced by children were significantly associated with increased provision of prophylactic antibiotics. Each visit for preventive care was associated with 12 additional days of prophylactic antibiotic coverage (95%CI 2.3 – 21.7). Each emergency department visit was associated with 10 additional days of coverage (95% CI 1.2 – 18.8).
| Administrative data | Tennessee, Washington State
Elliot, 2001 ^142^ | Patient adherence to prophylactic antibiotics | Patients (Children/Caregivers) | 50 | More children at home | More adults at home, having a car | Patient age, parental education | A higher number of adults living in the home and having a car were positively associated with compliance (p<0.01). A higher number of children in the home was negatively associated with compliance (p<0.01). The number of days between refills tended to increase as the child's age increased (p = 0.15). Maternal education was not significantly associated with compliance (p = 0.25). The authors assessed the utility of the Health Belief Model (HBM) in predicting parental compliance with prophylactic penicillin administration and did not find that any of the assessed variables (parent's perceptions of the seriousness of infection in young children with SCD, the perceived susceptibility of their child to infection, the perceived benefit of prophylactic penicillin in preventing infection, and the perceived burden of penicillin administration) were significantly associated with compliance after adjustment for demographic factors (p = 0.61).
| Family report, Administrative records | Unknown location
Teach, 1998 ^143^ | Patient adherence to prophylactic antibiotics | Patients (Children/Caregivers) | 123 | NR | Private insurance, younger patient age | Patient sex, SCD type | Measured compliance was significantly greater in patients <5 years of age than in those >5 (64% vs. 34%, p=0.004). Patients with private insurance (p=0.02) had better measured compliance than patients with public insurance. Sex, type of hemoglobinopathy, recruitment site (ED vs. clinic), and chief complaint in ED (fever vs. VOC) were not significantly associated with measured compliance.
| Patient report, family report, biologic outcome (urine assay) | Buffalo, NY
Witherspoon, 2006 ^169^ | Patient adherence to prophylactic antibiotics | Patients (Children/Caregivers) | 30 | NR | Caregiver knowledge, intent to adhere, perceived benefits, family employment | NR | Based on pharmacy records, one-third of caregivers had poor (14–30 days/month not ‘covered’ with antibiotic) and one-third had less than optimal (2–7 days/ month ‘uncovered’ with antibiotics) levels of adherence to penicillin prophylaxis. Caregiver knowledge of infection and intent to adhere positively predict adherence. Caregivers with better adherence had more knowledge of infection, greater intent to adhere or greater belief in the importance of the medication (p<0.05), and reported fewer barriers to adherence (p<0.01). Families with better adherence rates were more likely to be employed (p<0.01), and reported fewer barriers to adherence (p <0.05).
| Provider report, family report, administrative data | USA
Pejaver, 1997 ^170^ | Patient adherence to prophylactic antibiotics | Patients (Children/Caregivers) | 41 | NR | NR | Patient/caregiver knowledge, patient age, patient sex, # of children in family, years on therapy, # of inpatient admissions | One quarter (24%) of parents demonstrated good knowledge of the reasons and need for penicillin prophylaxis, however knowledge was not associated with compliance levels in this study.
| Family report, presence of penicillin in urine | Saudi Arabia (armed forces hospital)
Jensen, 2005 ^144^ | Patient adherence to prophylactic antibiotics | Patients (Children/Caregivers) | 97 | NR | Caregiver knowledge for children <11 yrs, no child history of transfusions | History of stroke, hospital visits, # of missed appointments | In the overall sample, caregiver knowledge of SCD did not correlate with adherence with recommended SCD preventative behaviors (r=0.16, p=0.12). In post-hoc analyses, however, the authors found that caregiver knowledge of SCD was positively associated with adherence for children 11 years of age and younger, but not for children 12 and older (p<0.05).
| Family report | USA
Studies on Barriers to Receipt of Appropriate Pain Medication during Vaso-occusive Crisis
Labbe, 2005^155^ | Provider provision of pain medication | Physicians | 109 | Negative provider attitudes | Fewer provider years in practice, provider female gender | | Physician characteristics and attitudes may affect the quality of pain management delivered to patients with SCD. The earlier the year of graduation from medical school, the more likely a physician was to believe that opioids play major role in the development of addiction (r = -0.32, p<0.001), and also that drug addiction should be a primary concern when treating SCD patients (r = -0.26, p<0.008). Female physicians were more likely than male physicians to believe that the primary focus of treatment for a sickle cell crisis should be adequate pain relief (r = -0.20, p <0.04). Physicians who believed drug addiction should be a primary concern were less likely to believe the primary focus of treatment should be adequate pain relief (r = -0.20, p < 0.0037).
| Provider report | 7 federally funded comprehensive SCD centers in the USA
Armstrong, 1992^145^ | Provider provision of pain medication | Physicians (pediatric residents), Nurses | 92 | Hospital visits | NR | Provider attitudes, professional experience and training | Nurses, but not pediatric residents, recommended lower pain medication doses for frequently, as opposed to occasionally, hospitalized children as described in hypothetical history vignettes. However, there were no differences in pain ratings between nurses and residents across the vignettes. There were no significant correlations between nurse or resident pain ratings or medication decisions and their attitudes and beliefs about pain in children.
| Provider report | Unknown
Pence, 2007^146^ | Patient use of pain medication | Patients (Children/Caregivers) | 27 | NR | Dispositional optimism | Patient age, patient sex, parent education | For adolescent patients with SCD, pain severity was positively associated with opioid use such that high pain predicted higher use (p<0.001), and pain severity uniquely accounted for the largest proportion of the variance in opioid use (partial r-squared = 0.19). Dispositional optimism was found to moderate the relationship between pain severity and use of opioids (p<0.05). Specifically, at medium and high levels of optimism, pain severity was positively associated with opioid use. At low levels of optimism, pain severity was not associated with opioid use. At low levels of optimism, an intermediate level of opioids was used consistently regardless of whether pain severity was low or high. Additionally, maternal education was found to be marginally associated with adolescent opioid use (p = 0.08). Higher maternal education predicted more opioid use, while lower maternal education predicted more non-opioid use.
| Patient report, family report | North Carolina
Studies on Barriers to Receipt of Routine, Scheduled Care
Telfair, 2003^147^ | Use of routine health services | Patients (Adults and Children/Caregivers) | 662 | NR | Rural geographic region | Community socioeconomic distress, physical functioning, # of medical problems, distance to a clinic | In bivariate analyses, patients with SCD living in rural areas had lower utilization of comprehensive sickle cell services than patients living in urban areas (significance not reported). However, utilization of comprehensive sickle cell services is predicted to be higher for SCD patients in rural areas compared to those in urban areas after adjustment for distance to a clinic, community socioeconomic distress, physical functioning, and a medical problem index (p=0.003). While the model results suggested that utilization of services increased with increasing socioeconomic distress, the p-value for the result (p = 0.011) did not reach the author's threshold for statistical significance.
| Patient report, administrative data | Alabama
Logan, 2002 ^148^ | Use of routine health services | Patients (Children/Caregivers) | 70 | NR | Illness-related stress, greater parental/ family knowledge | Parent/adolescent relationship, disease severity, stressful life events, clinical maladjustment | The authors developed a multivariate model predicting the use of routine health services (scheduled clinic visits, calls to clinic, information seeking from clinic, management of pain symptoms at home). The frequency of illness-related stress accounted for the largest individual portion of the explained variance in routine service use (partial r=0.41, p<0.001). Having more frequent illness-related stress was associated with greater use of routine services. Greater parental knowledge of SCD also accounted for a significant portion of the variance in routine service use and predicted more use of routine services (partial r=0.33, p<0.001). Parental reports of the parent-adolescent relationship, disease severity, stressful life events, and clinical maladjustment were not significant predictors of routine service use.
| Patient report, family report, administrative data | Unknown
Wojciechowski, 2002 ^149^ | Transition to adult care | Patients (Adults and Children/Caregivers) | 18 | NR | Self-efficacy, female sex | Receipt of preparation for the transfer to adult care | In this study of adolescents and young adults making the transition to adult-centered care, patients with greater SCD self-efficacy kept a higher percentage of their care appointments (p<0.05 using Spearman rho test). Females exhibited better compliance with medical regimens than did males as indicated by higher scores on a scale assessing compliance. There was no significant association between receipt of preparation for the transfer to adult-centered care and compliance with medical regimens.
| Patient report, provider report | Unknown
Haque, 2000 ^150^ | Use of routine health services | Patients (Adults and Children/Caregivers) | 1189 | Greater community socio-economic distress | Rural geographic region | Distance to clinic, interference of disease in daily life, level of medical problems | Patients living in rural areas were estimated to have greater utilization of comprehensive sickle cell services than patients living in urban areas after adjustment for socioeconomic distress, interference of sickle cell disease in their daily lives, their self-reported level of medical problems, their distance to a comprehensive clinic, and a term representing the interaction of distance to a clinic and their level of socioeconomic distress (p <0.001). In this same model, patients living in areas with more socioeconomic distress were estimated to have less utilization of services (p = 0.04) after adjustment for the other factors. None of the other variables in the model were significantly associated with utilization.
| Patient report, administrative data | North Carolina
Barakat, 2002^151^ | General adherence to treatment regimens | Patients (Children/Caregivers) | 81 | NR | Greater parental/ family knowledge, family problem-solving effort, higher family income | NR | In multivariate models, greater SCD knowledge (p = 0.032) and greater family effort in solving family problems (p = 0.037) were significantly associated with higher medical staff rating of patient/ family adherence to treatment regimens. Greater family income was marginally associated with higher medical staff ratings of adherence (p = 0.053).
| Provider report, patient report, family report, administrative data | Unknown
Belgrave, 1994 ^152^ | Appointment-keeping | Patients (Adults) | 49 | NR | Social support | NR | Social support, defined in this study as the frequency of supportive and helpful behaviors performed by others, was positively correlated with self-report of medical appointment keeping (r = 0.47, p 0.05). Patients with greater social support had better self-reported rates of keeping medical appointments
| Patient report | Washington, DC

CI = confidence interval; ED = emergency department; HBM = Health Belief Model; HRQOL = health-related quality of life; HU = hydroxyurea; IQR = interquartile range; NR = not reported; SCD = sickle cell disease; SD = standard deviation; VOC = vaso-occlusive crisis.

Evidence Table 26. Barriers to Care of Sickle Cell Disease Reported by Patients and Providers

Author, year | Study design | Study population | N | Barriers identified | Primary results
| | | Location
Studies on Barriers to Receipt of Treatments to Increase Hemoglobin F
Zumberg, 2005 ^93^ | Quantitative: questionnaires (27-item, 4-page self-administered questionnaire) | Doctors (hematologists) | 184 | Patient compliance, lack of contraception, patient anticipation of side effects, patient age, provider concern about side effects, provider doubting effectiveness, cost | There were differences in HU prescribing between community and academic physicians showed differences in HU prescribing in the treatment of ACS (43% vs. 70%, p=0.006), stroke (40% vs. 60%, p=0.04), and pulmonary hypertension (7% vs. 23%, p=0.008). Community physicians less frequently monitored compliance by pill count (7% vs. 20% in academic physicians, p=0.03) and MCV measurements (36% vs. 90%, p<0.0001). Concerns that were identified as “important” or “very important” barriers to the use of HU were patient compliance (90%), lack of contraception (79%), patients' anticipation of side effects (82%), patient's age (50%), cost (59%), concern about carcinogenic potential (40%) and doubting effectiveness (40%).
| | Florida, North Carolina
Studies on barriers to patient adherence to established therapies for disease-management
Witherspoon, 2006 ^169^ | Quantitative: questionnaires | Patients (children/caregivers) | 30 | Caregiver being busy, forgetting to administer medications, child falling asleep, running out of medication | Commonly reported barriers to adherence were: the caregiver being busy (26.7%), forgetting to administer the medication (23%), the child falling asleep (20%), and running out of medication (16.7%)
| | USA
Pejaver, 1997 ^170^ | Quantitative: questionnaires | Patients (children/caregivers) | 41 | Forgetting, disliking taste, concern about side effects | Common reasons given for non-compliance with penicillin were forgetting to give the medicine, forgetting to renew the supply of medicine, the child not liking the medicine, and the feeling that daily medication could have ill effects.
| | Saudi Arabia
Studies on Barriers to Receipt of Appropriate Pain Medication during Vaso-occusive Crisis
Booker, 2006 ^159^ | Qualitative: focus groups | Patients (adults) | 10 | Negative provider attitudes | Participants likened dealing with healthcare professionals to a battle. They felt that they had to work hard to convince the doctors that they were in genuine pain and need of help. Some patients felt so disbelieved that they actively avoided consulting when in crisis, for fear of being perceived as opioid dependent. Many patients felt that doctors did not have sufficient knowledge of sickle cell disease to make valid treatment decisions.
| | UK
Rouse, 2004 ^160^ | Qualitative: observations made while performing anthropological research on two children's hospitals | Nurses, doctors, patients (adults) | NR | Negative provider attitudes | In the wards, residents and nurses dismissed patients' demands for pain relief as drug addiction, malingering, or manipulation. Furthermore, several staff members stated that “patients were being denied proper medical care, unfairly accused of drug use or criminal behavior, transferred to adult care clinics at an early age, and generally treated with less respect than the cancer patients who occupied the same floor in the hospital.” With few exceptions, the nurses' perceptions of their sickle cell patients were overwhelmingly negative. During one session, it was revealed that while nurses believe cancer patients' self-reporting of pain, they generally believed that their sickle cell patients inflated their level of pain. One nurse said, “One of the problems with sickle patients, I believe, is that healthcare professionals make a connection between African-Americans using drugs and existing stereotypes; and that is coupled with {health care professionals'} lack of knowledge about sickle cell disease.”
| | California and Pennsylvania
Pack-Mabien, 2001 ^153^ | Quantitative: questionnaires (written 31-item multiple choice survey about nurses' attitudes and perceived barriers to opioid pain management of sickle cell patient pain episodes) | Nurses | 200 | Negative provider attitudes, lack of provider knowledge, lack of time, inadequate pain assessment tools | Many nurses believed that drug addiction frequently develops in sickle cell patients (63%) and reported (49%) that they did not have broad knowledge of sickle cell disease. 59% reported Inadequate pain assessment tools were reported by 59% as the greatest barrier in the management of pain episodes. Lack of time for psychological support of patients (58%), nurse reluctance to provide opioids (37%), a narrow range of available analgesics (37%), physicians' reluctance to prescribe opioids (33%), and the belief that most sickle cell patients are drug addicts (32%) also reported barriers.
| | USA
Maxwell, 1999 ^161^ | Qualitative: 18 semistructured interviews with 15 individuals and 8 focus groups | Patients (adults) | 57 | Negative provider attitudes | In focus groups, patients reported negative experiences with hospital care. These were characterized by mistrust (being suspected by health professionals of exaggerating pain), stigmatization (treated differently from other inpatients—“drug addicts”), control (health professionals exerted control and failed to involve patients in decision-making), neglect (of personal care, monitoring of vital signs, and psychosocial support due to understaffing or low priority). A minority of patients responded to unsatisfactory care by self-discharging from one hospital and going to another.
| | London
Waters, 1995 ^168^ | Mixed: questionnaires (self-administered in presence of research coordinator) with qualitative analysis of open-ended responses. | Nurses (inpatient), patients (adults) | 26* | Negative provider attitudes, lack of provider knowledge, lack of time | Factors reported by the subset of 13 nurses who felt they could better relieve sickle cell pain were time (4/13), lack of knowledge of narcotic analgesia (4/13), fears of overdosing and addiction (4/13), and lack of experience with sickle cell patients (2/13). Most patients (7/9) felt less in control of pain while in the hospital as compared to at home and wanted to be more involved in management of pain while on the ward. All patients stated they had to ask if they wanted more analgesia although the “majority” of nurses said they assessed pain continually. The majority of patients considered nurses' knowledge of sickle cell crisis and sympathy towards them as a patient group to be poor. Evidence of unsatisfactory pain management evidenced by comment from patient: “. . . You can just tell sometimes that they don't agree with having to give you the injection”
| | UK
Tucker, 1995 ^162^ | Qualitative: focus groups | Patients (adults) | NR | Negative provider attitudes, lack of provider knowledge | In 12 support group sessions of 2–8 patients each, patients all agreed on two major problem areas: (1) obtaining appropriate medical care in the ER (time to admission, feeling “forgotten”, would delay hospital visits out of “dread”) and (2) difficulty relating to members of the health care team (poor communication, “providers did not believe them”, pain medication “not strong enough”, discharged “too soon”, being told “the pain is all in your head.” Also, patients noted lack of knowledge by providers, felt "they are encouraged to ‘act out’ the pain in order to be taken seriously and medicated appropriately. Several group members said that “they would do everything possible” to keep from coming to the hospital because they dreaded the admission procedures.
| | California
Alleyne, 1995 ^163^ | Qualitative: in-depth semi-structured individual and group interviews | Nurses (inpatient), patients (adults) | 20^†^ | Negative provider attitudes, patient race | All 10 patients and 4 nurses expressed dissatisfaction with pain management. Patients (7) reported they had to demand painkillers and wait at least 30 minutes. Patients (8) believed the nurses doubt the genuine nature of the pain, all patients reported lack of involvement in pain control, and all reported that nurses were not sympathetic to pain, telling them, “you'll have to wait.” One patient said, “I've got the feeling that some of them purposely prolong it.” One nurse suggested that there might be a link between young black people and drug-taking which caused nursing staff to be suspicious of the patients' request for pethidine. Nurses reported frustration with relying on physician orders for narcotics and 2 nurses reported that patients could not be “trusted to be responsible” with patient-controlled analgesia.
| | UK
Shelley, 1994 ^164^ | Qualitative: phone interviews | Patients (adults, SCD self-help group leaders) | 11 | Negative provider attitudes, lack of provider knowledge | Patients perceived problems in health care services delivery. Inadequate staff training and high turnover in the ED, health providers' fears of drug addiction, negative attitudes of physicians to patients, delays in ED, unfamiliarity of staff with SCD, routine accusations of drug-seeking, insensitivity of physicians to patients' pain, and negative reactions by physicians to patient attempts to be involved in the course of their own care were all reported. Most group leaders cited the unfamiliarity of ER staff with SCD as a factor which contributes to delays in treatment of VOCs. Several group leaders also cited provider insensitivity to patients' pain as a problem. Almost half of group leaders reported negative reactions on the part of some physicians to patients, including ignoring a patient, blunt remarks about the doctor's amount of knowledge vs. the ‘lay’ patient. Group leaders reported that these sorts of incidents keep some SCD patients from the ED, even when they are in pain.
| | USA
Strickland, 2001 ^165^ | Qualitative: focus groups | Patients (adults), family members | 21^‡^ | Negative provider attitudes | In focus group sessions, adults with SCD stated the belief that nurses would not give them pain medications when needed because the nurses believed that persons with SCD are addicts. Adults with SCD also stated the belief that some medical providers are intimidated when patients demonstrate knowledge about their disease or their pain control.
| | USA
Murray, 1988 ^154^ | Quantitative: questionnaires | Patients (adults) | 102 | Negative provider attitudes | Of the 88 patients who went to the hospital for care, 18 thought they were seen quickly, 33 thought the delay was too long, 17 were concerned about side effects of medications, 40 said pain relief “was there when needed”, but only 23 routinely received analgesics on demand, and 57 patients thought staff did not appreciate the amount of pain they were having.
| | UK
Harris, 1998 ^166^ | Qualitative: standardized, structured open-ended interviews | Patients (adults) | 27 | Negative provider attitudes | Study participants were satisfied with pain relief (78%), but 30% stated pain control would be improved with more prompt administration of meds. Overall hospital service was reported as “satisfactory to good” by 63%, but 44% made a complaint about the staff's negative attitude to people with SCD, 26% felt staff generally lacked knowledge and understanding of SCD and pain crises, 22% said staff did not believe or appreciate that they were in pain (“they treat us like liars”) and 19% said nurses were slow to give analgesia and attended to other “less urgent” tasks (such as “pillows”).
| | UK
Labbe, 2005 ^155^ | Quantitative: questionnaires | Doctors | 109 | Negative provider attitudes, inadequate pain assessment tools | Physicians hold a number of beliefs and attitudes which may affect the quality of pain management delivered to patients with SCD. While the patient's self-report of pain was the tool most commonly used by physicians in assessing the severity of pain (92% of respondents), 86% of the physicians “somewhat disagreed to disagreed” that the most reliable indicator of the existence and intensity of pain is the patient's self-report. Physiological and behavioral measures were also commonly cited tools used to assess pain severity. The top 5 barriers to optimal pain management in SCD as reported by these physicians were lack of psychological support from patient's family and the medical profession, fear that the patient is a drug abuser, reluctance to prescribe opioids, disbelief in patient's report of pain severity, and inadequate pain assessment tools.
| | Alabama
Butler, 1993 ^167^ | Qualitative: authors' reports of themes that arose in a SCD support group that included medical residents | Patients (adults) | 24 | Negative provider attitudes | During their lives, each member of the group had experienced many negative interactions with health care providers, including routinely being treated with suspicion and distrust. Patients expressed extreme frustration in attempting to convince health professionals of their distress.
| | USA
Studies on Barriers to Bone Marrow Transplantation
Walters, 1996 ^158^ | Quantitative: questionnaires (bone marrow consortium participants were asked to report on barriers at their institutions) | Physicians | 315 | Lack of donor, lack of financial/psychosocial support, parental refusal, physician refusal, history of non-compliance | 315 out of 4,848 patients from 22 centers were reported to be eligible for bone marrow transplantation (BMT). Of the 315, 187 did not undergo HLA typing. The reasons for this included lack of HLA matching donor (76/187), lack of support (33/187), parental refusal (30/187), and physician refusal (13/187). Among those who had an HLA-identical donor (44), parental refusal was the most frequent reason for not performing a BMT.
| | USA (multi-center study)
Studies on Barriers to Non-specific ‘Treatment’ or Healthcare ‘Quality’
Telfair, 1998 ^156^ | Quantitative: questionnaires (providers were asked to agree or disagree with 3 questions about (1) quality of health care provided to persons with SCD, (2) decisions about the administration of pain medication, (3) quality of interpersonal relationships between health care providers and patients) | Nurses, doctors, physician assistants, social workers | 227 | Patient race | Providers generally disagreed that race influences delivery of health care to individuals with SCD (52% disagree that quality is influenced, 77% disagree that pain medication decisions are influenced, 52% disagree that quality of interpersonal relationships are influenced). In bivariate analyses, 76% African-American vs. 35% Caucasians (p<0.00) agreed that race is an influence on quality, and 30–54% females vs. 12–37% males (p<0.01) agreed with all three statements regarding race as an influence on health care provision. More urban providers (26%) vs. rural providers (11%) agree that race influences pain medication decisions (p<0.02). In multivariate analysis, AA provider race was associated with all three questions (p<0.01): quality (or 5.6, 95% CI: 2.80,11.22); pain medication decisions (or 3.1, 95%CI: 1.54,6.19); quality of relationships (or 3.9, 95%CI: 2.02,7.38)
| | USA
Chestnut, 1994 ^171^ | Qualitative: structured interview and service perception test (spt) in which subjects had to choose patients (via pictures) who they felt would receive better care | Nurses, doctors (hematologists), medical staff, patients (children/caregivers) | 29^§^ | Patient race, patient sex, patient age | Family respondents perceived that younger children get the best care (regardless of gender or race), that whites get better service than blacks (regardless of age or gender), and that females get better care than males. Medical staff also perceived that children, whites, and females get better care than adults, blacks, and males.
| | USA
Vichinsky, 1999 ^157^ | Quantative: questionnaires (directors and associates of SCD centers were asked to comment on provision of care by community physicians using a survey tool developed for this study) | Directors and associates of sickle cell disease centers | 21 | Lack of provider knowledge | In most categories, over 90% of respondents stated that care provided by physicians from their centers complied with NIH guidelines, as compared to many fewer (50% or less) who reported that care by community physicians complied with NIH guidelines in all categories except care related to infection (60%) and contraception and pregnancy care (59%). Most respondents (72%) believed that lack of knowledge or training was the reason that community physicians failed to follow NIH guidelines.
| | USA, Canada

* 9 patients and 17 nurses

† 10 nurses and 10 patients

‡ 10 patients and 11 family members

§ 22 patients and 7 staff

AA = African American; ACS = acute chest syndrome; BMT = bone marrow transplant; CI = confidence interval; ED = emergency department; ER = emergency room; HU = hydroxyurea; MCV = mean corpuscular volumes; NIH=National Institutes of Health; NR = not reported; OR = odds ratio; SCD = sickle cell disease; SPT = service perception test; VOC = vaso-occlusive crisis.

Evidence Table 27. Description of Interventions to Improve the Receipt of Routine Care, and Appropriate Medications for Sickle Cell Disease

Author, year | Study design | Study population | N | Intervention objective | Intervention description
| | Study location | | Main intervention components
Studies on Interventions to Improve Receipt of Appropriate Pain Medication during Vaso-occusive Crisis
Mitchell, 2002 ^172^ | Pre-post | Nurses, doctors, social workers, patients | 27 | To improve the consistency and quality of care for patients with SCD having a VOC at a 200-bed community hospital. | Implementation of new mandatory pain management protocol emphasizing aggressive pain management in the ED (using morphine sulfate or dilaudid rather than meperedine), admission to medical-surgical unit if crisis not resolved in 8 hours, and continued PCA, IV fluids, and oxygen. Physicians and nurses received in-service training related to the new protocol. One case manager was also assigned to coordinate all care.
| | Philadelphia, PA | | Clinical protocol/pathway
Co, 2003^173^ | Pre-post, CCT | Patients (children/caregivers) | 369 | To improve the care for pediatric SC VOCs | Clinical pathway for the treatment of children aged 2 – 19 years with VOC requiring hospitalization. Use of IV fluids, incentive spirometry, and pain service consultation were main check points for the pathway.
| | Baltimore, MD | | Clinical protocol/pathway
Jamison, 2002 ^174^ | Pre-post | Nurses, doctors, patients | 204 | 1) To improve overall satisfaction of patients with SCD who were cared for at the study hospital (tertiary care hospital in the southeast); 2) To reduce the length of stay of patients with SCD; 3) To reduce the costs associated with hospital treatment of patients with SCD. | Intervention included staff education (sensitivity training, information about SCD, pain management and other treatment interventions), nurse education about complementary therapies and other diversional activities, and a protocol to be used which included standing orders to evaluate and treat crises. Patients who did not have adequate control within 8 hours and who were moved to inpatient area were all admitted to oncology ward rather than diverse departments. Patient education materials, safety guidelines for admission, identification cards and discharge instructions (including document with education and resources) were developed.
| | Greensboro, NC | | Clinical protocol/pathway with sensitivity training
Cooper, 2000^175^ | CCT, Pre-post | Nurses, doctors | 67 | 1) Develop individualized pain management protocols; 2) Discourage the use of meperedine in favor of morphine, hydromorphone, and levorphanol; 3) To use buprenorphine for patients with known or suspected narcotic dependence. | The intervention was developed by establishing consensus concerning guidelines for care of SCD patients, and then educating physicians, nurses and house staff on new guidelines via Grand Rounds, conferences, medical management conferences, informal presentations, audiotapes and mailings. Patients were identified via admitting diagnosis and a care manager or physician made recommendations based on guidelines. Individualized care plans were constructed for “frequently admitted” sickle cell patients and were entered into mainframe for access by all physicians.
| | Cleveland, OH | | Clinical protocol/pathway
Benjamin, 2000 ^176^ | CCT, Pre-Post | Nurses, doctors, social workers, patients | 144 | To decrease the load of the ED and to study the value of a dedicated facility with knowledgeable staff applying principle-based individualized care. | Establishment of a Day Hospital with comprehensive assessment and treatment protocol (assessment and initial treatment within 15–20 minutes of arrival followed by assessment with established instruments every 30 minutes). Protocol included assessment, individualized drug management, medication titration to relief, maintenance of relief, use of combination drugs to enhance efficacy/toxicity ratio, monitoring of adverse events, identifying and treating precipitating factors, and appropriate disposition.
| | Bronx, NY | | Establishment of Day Hospital
Day, 1997 ^177^ | Pre-post | Nurses, doctors, patients | 18 | To retrospectively audit admissions of SCD patients to identify problems with pain management and look for improvements after the care guidelines were introduced to department. | One nurse audited 10 admissions prior to implementation and 8 admissions after implementation to evaluate time to receive analgesia, what was prescribed, dose and method of administration, whether the pain management team was called, whether patient-controlled analgesia was used, and to which ward patient admitted. Data from the initial audit were shared with providers.
| | UK | | Audit and Feedback
Brookoff, 1992 ^178^ | Pre-post | Nurses, doctors, patients (adults) | 50/year | To determine if providing adequate pain control (using continuous morphine infusions and sustained courses of orally administered controlled-release morphine) for the treatment of SCD in adults can decrease hospital visits and admissions for sickle cell pain. | Intravenous and oral controlled-release morphine was used instead of intramuscular meperidone and short-acting opiods in treatment of pain.
| | Philadelphia, PA | | Clinical protocol/pathway
Fertleman, 1992^179^ | Pre-post | Nurses, doctors, patients (children/caregivers) | 72 | To evaluate the efficacy of fast track system in which children with SCD are directly admitted to the ward after a telephone call from parent, assessed immediately, and given intramuscular pethidine if indicated (dose pre-prescribed). | Fast track system in which children with SCD are directly admitted to the ward after a telephone call from parent, assessed immediately, and given a (pre-prescribed, documented) dose of intramuscular pethidine if indicated. Time to treatment pre- (1994) and post-implementation (1995) were compared. Parents (25) whose children had used both systems completed questionnaires about both.
| | London, UK | | Establishment of fast track admission procedures
Treadwell, 2002 ^180^ | Pre-post | Hospital staff, patients (children/caregivers) | 235 | To implement developmentally appropriate pain assessment guidelines for pediatric inpatients | Staff were educated on the use of pediatric pain assessment tools and a standardized pain assessment protocol was put into practice.
| | USA | | Clinical protocol/pathway
Studies on Interventions to Improve Patient Adherence to Therapies
Treadwell, 2001^181^ | Pre-post | Patients (children/caregivers) | 11 | To increase patients' knowledge of the disease and treatment regimen within a setting that encouraged and assisted peer interactions, and ultimately to enhance treatment adherence. | Desferel Day Camp - provided peer support and education for 4 days each summer.
| | California | | Education and peer support
Berkovitch, 1998^182^ | RCT | Patients (children/caregivers) | 23 | To establish a simple method of improving compliance with antibiotics in children with SCD. | Intervention subjects attended slide show (describing pathophysiology of SCD, risk of infections, importance of antibiotics), received stickers and a calendar to document compliance, and got a weekly phone call from social worker (asking questions about treatment, general health, other meds, family problems). Control and intervention subjects were invited to clinics every 8 weeks, where meds were dispensed and compliance evaluated. At end of 6 months, parents in both groups completed a questionnaire to determine knowledge and understanding of SCD.
| | Toronto,Canada | | Education and follow-up by medical professionals
Ketchen, 2006^183^ | RCT | Patients (children/caregivers) | 37 | To evaluate the efficacy of the home version of Starbright World, a Web-based computer network designed to connect chronically ill children, on increasing knowledge of SCD, increasing engagement in health-promoting activities, and improving psychosocial functioning. | Access to Starbright World with weekly assignments (educational and social activities and those that encouraged child-parent participation). Staff member called caregiver weekly.
| | US, Canada | | Education and peer support
Studies on Interventions to Improve Patient Receipt of Routine, Scheduled Care
Patik, 2006 ^184^ | Pre-post | Patients (children/caregivers) | 202 | To determine the feasibility and acceptance of the intervention for families with a child with SCD and the impact of the intervention on adherence to comprehensive care. | Telephone-delivered structured follow-up, support and education by non-medical personnel (graduate student researcher). The semi-structured script included questions related to patient's well-being and health-related behaviors and was administered at 3-month intervals from the last contact.
| | Pittsburgh, PA | | Education and non-medical follow up support

CCT = clinically controlled trial; ED = Emergency department; IV = intravenous; LOS = length of stay; PCA = patient controlled analgesia; RCT = randomized controlled trial. SCD = sickle cell disease; VOC = vaso-occlusive crisis.

Evidence Table 28. Results of Interventions to improve the Receipt of Routine Care, and Appropriate Medications for Sickle Cell Disease

Author, year | Primary outcome (directness) | Outcome measurement | Primary results | Summary
Studies on Interventions to Improve Receipt of Appropriate Pain Medication during Vaso-occusive Crisis
Mitchell, 2002 ^172^ | Utilization (indirect) | Administrative data were used. Outcomes were measured 6 months before and 6 months after protocol. | There were 235 visits to the ED with 76 admissions (68% treat-and-release) pre-intervention compared to 188 visits to the ED with 46 admissions (76% treat-and-release) post intervention. The average length of stay decreased from 4.9 days to 3.8 days. The authors report that there were no patient complaints during the intervention and that patients commented that “pain was being managed more efficiently.” There was no significance testing reported in the article. | Potential improvement
Co, 2003 ^173^ | Pain management quality (direct) | Administrative data (use of IV fluids, incentive spirometry, and pain service consultation) were used. | Of 369 patients, 139 were admitted before the pathway, and 230 were admitted after the pathway. Physicians used the pathway 43% of the time after the pathway became available. Pathway patients were more likely than non-pathway patients to have received IV fluids (OR=1.15, 95% CI 1.07 –1.23), incentive spirometry (OR=2.49, 95% CI 2.02–3.07), and pain service consult (OR=1.33, 95% CI 1.18 – 1.50). Pathway patients had longer length of stay (p=0.01) and time to oral pain medication (p<0.001) than non-pathway admissions. No difference in readmission rates. | Improvement
Jamison, 2002 ^174^ | Patient ratings, utilization, costs (direct) | Patient reports, administrative data were used | A pain management questionnaire administered to 9 patients at the beginning of implementation and to 10 patients 6 months later showed “marked improvement in the follow-up 6 month survey.” Patient satisfaction post questionnaire that asked patients about satisfaction pre and post implementation was administered to 18 patients, and suggested that satisfaction overall improved. There was an overall trend in decreasing LOS post-implementation. Admissions to the ED or inpatient departments decreased >50% post-implementation. There was an 18.5% decrease in inpatient costs and 29.6% decrease in costs of observation stays. There was no significance testing reported in the article. | Potential improvement
Cooper, 2000 ^175^ | Utilization, costs, pain management quality (direct) | Administrative data were used | Of 58 care-managed admissions (study group) and 9 non-care-managed admissions (control group), the median unadjusted hospital length of stay was 3.5 days in the study group versus 4 days in the control group (p=0.54). Costs were $2,920 in study group versus $3,157 in control group (p=0.32). The use of non-guideline narcotic meperedine decreased from 82% pre-implementation to 18% post-implementation. (p<0.001). | Improvement
Benjamin, 2000 ^176^ | Utilization, pain management quality (direct) | Administrative data were used. | Walk-in DH patients discharged to home increased from 70% in first 2 years to 90–94% in last 3 years. The average length of stay in DH was 4.5 hours (range 2 to 7 hours) vs.13 hours (range 11 minutes to 90 hours) in the ED. Treatment time in the ED before transfer to DH was 16 hours in year 1 vs. 8 hours in year 5. Visits resulting in admission were lower for DH patients (8%) vs. ED patients (51%). Admission rate in patients with uncomplicated pain was 776/1818 (42.7%) ED patients vs. 168/2033 (8.3%) DH patients. The use of meperidine decreased from 90% in year 1 to 63% in year 5, while the use of hydromorphone increased from 3% (Year 1) to 33% (Year 5). There were no p-values reported. | Potential improvement
Day, 1997^177^ | Pain management quality (direct) | Administrative data were used. | After the intervention, the use of intramuscular pethidine decreased from 8/10 to 0/8 and the use of patient-controlled analgesia with morphine increased from 1/10 to 7/8. The incidence of calling the pain team promptly at admission increased from 1/10 to 8/8. The author reports that the time to see physician was “often. . .not immediate” prior to the intervention, but changed to “all. . . seen by a doctor immediately upon arrival” after the intervention. | Potential improvement
Brookoff, 1992 ^178^ | Utilization (indirect) | Administrative data and patient reports were used. | Following this intervention, the total number of emergency department visits declined by 67% (426 to 138), the number of admissions declined by 44% (115 to 65), and the duration of hospital stay decreased by 23% (7.12 days to 5.45 days). There were no p-values reported. New protocol “met with strong resistance by a few patients” but this was eased by allowing these patients to “participate in developing their own analgesic plan.” | Potential improvement
| | Data on admissions and duration of hospital stay were collected for patients with SCD for all admissions from Jan 1 to June 30 in the years 1985 to 1990. ED visit data was collected for Jan 1 to June 30, 1988-1990. The new protocol was implemented in 1989.
Fertleman, 1992^179^ | Pain management quality, patient ratings (direct) | Family reports and administrative data were used. | Median time to pethidine decreased from 38 min to 5 min (p<0.001). 21 of 25 questionnaires were returned and all parents preferred the fast track system. Parents “added that the ward staff knew more about SCD, knew their children, and did not ask irrelevant questions before giving pethidine” | Improvement
Treadwell, 2002^180^ | Pain management quality, patient ratings (direct) | Patient report, family report, administrative data | Patients, families, and staff reported increased pain assessment, improved staff responsiveness to patients' pain and greater satisfaction with assessment tools post-intervention (all p-values <0.05). Increased compliance with the assessment guidelines was confirmed by chart audit. | Improvement
Studies on Interventions to Improve Patient Adherence to Therapies
Treadwell, 2001 ^181^ | Patient adherence (direct) | Patient reports were used. | Participation in Desferel Day Camp did not result in increases in measures of patient knowledge, peer support, or adherence to therapy. | No improvement
Berkovitch, 1998 ^182^ | Patient adherence (direct) | Family reports, administrative data, and medication event monitoring system were used. | Compliance at 2–4 months was 79.0% (±31.4%) in intervention group vs. 66.0 (±20.2%) in control group (p=0.297). Compliance at 4–6 months was 82.0 (±34.7%) in intervention group vs. 65.8 (±25.3) in control group (p=0.366). There were no significant differences in admission rates, or in measures of parent knowledge of SCD. | No improvement
| | At 6 months, parents in both groups completed questionnaire.
Ketchen, 2006 ^183^ | Health promotion activities, parent-child relationships, child quality of life, child depression (direct) | Patient/family reports were used. Data collection occurred pre-intervention and 2 months post-intervention of SCD. | Intervention and control groups did not differ with respect to demographic, disease severity, pre-study computer ownership, or exposure to health education programs. Children in the intervention group had significant improvements in quality of life [child quality of life (lower scores better): pre: 32.70 (17.64) in intervention vs. 35.27 (17.08) in control Post: 29.90 (15.34) in intervention vs. 31.44 (25.05) in control time. Children in intervention group showed improvements in parent-child relationships [pre: 14.50 (6.19) in intervention vs. 17.82 (4.28) in control and post: 16.04 (4.75) in intervention vs. 17.18 (5.00) in control time. There was a non-significant trend towards children in the intervention group having improvements in depression scores. There were no significant differences between intervention and control groups in health promotion activities or child knowledge of SCD. | Partial Improvement
Studies on Interventions to Improve Patient Receipt of Routine, Scheduled Care
Patick, 2006 ^184^ | Rate of patient non-attendance at clinic for 2 years (direct) | Cross-sectional patient survey prior to the start of the intervention and repeated 18 months later. | 147 of the 202 patients (73.6%) were available and willing to talk. 64% of patients requested a service during the phone call (e.g. prescription refill, information, appointment scheduling). The proportion of patients who had not attended clinic for >2 years decreased from 19.7% to 9.9% (p=0.002) following intervention, and transcranial doppler compliance increased from 34% to 49% (p= 0.05). | Improvement

CI = confidence interval; DH = day hospital; ED = emergency department; IV = intravenous; LOS = length of stay; OR = odds ration; SCD = sickle cell disease.

Evidence Table 29. In Progress or Planned Trials involving Hydroxyurea from Clinicaltrials.gov

Title | Sponsor | Design, Intervention | Target N | Study start-end | Inclusion and exclusion criteria | Objective
Stroke With Transfusions Changing to Hydroxyurea (SWiTCH) | National Heart, Lung, and Blood Institute | Interventional, efficacy, randomized trial of transfusions and chelation versus HU and phlebotomy | 130 | Jul 2006 - NR | Inclusion: 5.0–18.9 years; HbSS; HbSβ^0^ thalassemia; Hb S/O Arab; overt clinical stroke after the age of one year with documented infarction on imaging; ≥18 months of chronic monthly transfusions since stroke; transfusional iron overload; average hemoglobinS ≤ 45% in the 6 months prior to study entry | Aimed at demonstrating prevention of secondary stroke and management of iron overload.
| | (Phase III) | | | Exclusion: Inability to receive or tolerate chronic red blood cell transfusion therapy due to the following: multiple red blood cell alloantibodies or autoantibodies, religious objection to transfusions, non-compliance with transfusions in the 6 months prior to study entry; inability to take or tolerate daily oral HU; HIV infection; cancer; pregnant or breastfeeding; previous stem cell transplant or other myelosuppressive therapy; clinical and laboratory evidence of hypersplenism; transfusion requirement greater than 250 mL/kg in the 12 months prior to study entry; abnormal laboratory value at initial evaluation including: pre-transfusion hemoglobin concentration less than 7.0 gm/dL; white blood cell count less than 3.0 × 10^9^/L; absolute neutrophil count less than 1.5 × 10^9^/L;, platelet count less than 100 × 10^9^/L; serum creatinine more than twice the upper limit for age OR greater than or equal to 1.0 mg/dL; current participation in other therapeutic trials; current use of other therapeutic agents for sickling

0 eGFR = estimated glomerular filtration rate; Hb = hemoglobin; NR = not reported; S β thal = Sickle β thalassemia; Hb S/O Arab = hemoglobin SO Arab; SC = Sickle-Hemoglobin C Disease; SCA = sickle cell anemia; SS = Sickle Hemoglobin SS Disease; SWiTCH = Stroke With Transfusions Changing to Hydroxyurea; VOC = vaso-occlusive crisis.

Evidence Table 30. Analyses in Progress from the Multicenter Study of Hydroxyurea

Analysis | Investigators
Treatment effect on daily pain / D-02 (Measurement of pain in sickle cell anemia) / D22 (Pattern of utilization of health care facilities by adult patients with SS) / D-08 (Effect of weather on sickle cell) | Smith, Ballas, McCarthy, and the MSH Investigators
Analgesia usage in sickle cell patients | Ballas, Smith, Castro, Bellevue, B. Barton and MSH Investigators
A surrogate end point for sickle cell crisis from pain diaries / Development of multivariate predictive model of painful episodes in sickle cell anemia | Swerdlow, Smith, Ataga and the MSH Investigators.
Long-term mortality in sickle cell patients using HU | Saunthararajah, Ataga, Barton, McCarthy, other investigators
Pulmonary hypertension in sickle cell patients using HU | Castro, Ataga, B. Barton
Effect of discontinuation of HU on effectiveness / D-17 Non-response to HU therapy | Ballas, Swerdlow, Orringer and the MSH Investigators.
Long-term effects of hydroxyurea usage on laboratory measurements | Kutlar, Eckman, B. Barton
Dense cells and reticulocytes in sickle cell patients / A-02 (Effects of HU on RBCs in sickle cell anemia / D-19 (Technicon data) | Ballas, Orringer, Dover, B. Barton
Iron deficiency and the response to HU | Castro, Ballas, Barton, and the MSH Investigators.
Reproductive outcomes in sickle cell patients using HU | DeCastro, McCarthy, and the MSH Investigators
Results of the Vineland survey administered to sickle cell patients | Armstrong, Kutlar, B. Barton
Cytogenetic abnormalities in sickle cell patients / D-05 (Unusual alpha globin gene haplotypes in sickle cell anemia / A-08 (Analysis of DNA mutations associated with HU therapy | Kutlar, Saunthararajah, B. Barton
Clinical manifestations of sickle cell disease / D-10 (Defining a sickle cell crisis) / D-15 (GU Complications) / D-16 (AE of HU on liver and kidney function) | Ballas and the MSH Investigators.
Factors affecting compliance | Earles A, Jones S, Barton F.
Leg ulcers and HU | Kutlar, Ballas, Barton
Career and employment in Hb SS before and after HU treatment | Ballas, Barton
Objective laboratory parameters in SCD patients that predict chronic organ damage or survival | Saunthararajah, Ataga, Barton

AE = adverse event; DNA = deoxyribonucleic acid; GU = genitourinary; Hb = hemoglobin; Hb SS = sickle hemoglobin SS disease; HU = hydroxyurea; MSH = Multicenter Study of Hydroxyurea; SCD = sickle cell disease.