# Appendix B: Screen and Data Abstraction Forms

To see the Screen and Data Abstraction Forms, please select the link below. This link will take you to a PDF version of the forms.

Screen and Data Abstraction Forms