# Appendixes

Appendix A: Detailed Search Strategies

Appendix B: Screen and Data Abstraction Forms

Appendix C: Evidence Tables

Appendix D: Excluded Articles

Appendix E: Evidence Grading

Appendix F: Technical Experts and Peer Reviewers