# List of Acronyms/Abbreviations

AcMPAG | Acyl Glucuronide Metabolite of Mycophenolic Acid
AHRQ | Agency for Healthcare Research Quality
AMED | Allied and Complementary Medicine
AUC | Area Under the -Curve
CI | Confidence Interval
CNI | Calcineurin Inhibitor
CMV | Cytomegalovirus
C_0_ | Predose Trough Serum or Plasma Concentration
C_MAX_ | Maximum Serum or Plasma Concentration
ECrCl | Estimated Creatinine Clearance
ECMPS | Enteric-coated Mycophenolate Sodium
EMIT | Enzyme-Multiplied Immunoassay Technique
fMPA | Free Mycophenolic Acid
GFR | Glomerular Filtration Rate
HPLC | High-Performance Liquid Chromatography
HPLC-MS | High-Performance Liquid Chromatography-Mass Spectrometry
HRR | Hazard Rate Ratio
IMPDH | Inosine 5′-Monophosphate Dehydrogenase
LSS | Limited Sampling Strategy
MDR | Multidrug Resistance
MRP | Multidrug Resistance Protein
MMF | Mycophenolate Mofetil
MPA | Mycophenolic Acid
MPAG | Mycophenolic Acid Glucuronide
MU-EPC | McMaster University Evidence-Based Practice Center
OAT | Oroanal Transit Time
OCTT | Orocecal Transit Time
PK | Pharmacokinetic
QUALYs | Quality Adjusted Life Years
RCT | Randomized Controlled Trial
ROC | Receiver Operator Characteristic
RR | Relative Risk
SNP | Single Nucleotide Polymorphisms
SRS | Systematic Review Software
TDM | Therapeutic Drug Monitoring
TEP | Technical Expert Panel
TOO | Task Order Officer
UGT | Uridine Diphosphoglucuronosyltransferase