# References

1 Granger DK. Enteric-coated mycophenolate sodium: results of two pivotal global multicenter trials. Transplant Proc. 2001;33(78):3241-4. [pmid: 11750389].
2 de Winter BC, Mathot RA, Van Hest RM, et al. Therapeutic drug monitoring of mycophenolic acid: does it improve patient outcome?. Expert Opin Drug Metab Toxicol. 2007;3(2):251-61. [pmid: 17428154].
3 van Gelder T, Shaw LM. The rationale for and limitations of therapeutic drug monitoring for mycophenolate mofetil in transplantation. Transplantation. 2005;80(2 Suppl):S244-S253. [pmid: 16251857].
4 Arns W, Cibrik DM, Walker RG, et al. Therapeutic drug monitoring of mycophenolic acid in solid organ transplant patients treated with mycophenolate mofetil: Review of the literature. Transplantation. 2006;82(8):1004-12. [pmid: 17060847].
5 Budde K, Glander P, Diekmann F, et al. Review of the immunosuppressant enteric-coated mycophenolate sodium. Expert Opin Pharmacother. 2004;5(6):1333-45. [pmid: 15163278].
6 van Gelder T, Le Meur YL, Shaw LM, et al. Therapeutic drug monitoring of mycophenolate mofetil in transplantation. Ther Drug Monit. 2006;28(2):145-54. [pmid: 16628123].
7 Meiser BM, Pfeiffer M, Schmidt D, et al. Combination therapy with tacrolimus and mycophenolate mofetil following cardiac transplantation: importance of mycophenolic acid therapeutic drug monitoring. J Heart Lung Transplant. 1999;18(2):143-9. [pmid: 10194038].
8 Meiser BM, Pfeiffer M, Schmidt D, et al. The efficacy of the combination of tacrolimus and mycophenolate mofetil for prevention of acute myocardial rejection is dependent on routine monitoring of mycophenolic acid trough acid levels. Transplant Proc. 1999;31(12):84-7. [pmid: 10083018].
9 Flechner SM, Feng J, Mastroianni B, et al. The effect of 2-gram versus 1-gram concentration controlled mycophenolate mofetil on renal transplant outcomes using sirolimus-based calcineurin inhibitor drug-free immunosuppression. Transplantation. 2005;79(8):926-34. [pmid: 15849545].
10 Le Meur Y, Buchler M, Thierry A, et al. Individualized mycophenolate mofetil dosing based on drug exposure significantly improves patient outcomes after renal transplantation. Am J Transplant. 2007;7(11):2496-503. [pmid: 17908276].
11 Hale MD, Nicholls AJ, Bullingham RE, et al. The pharmacokinetic-pharmacodynamic relationship for mycophenolate mofetil in renal transplantation. Clin Pharmacol Ther. 1998;64(6):672-83. [pmid: 9871432].
12 van Gelder T, Hilbrands LB, Vanrenterghem Y, et al. A randomized double-blind, multicenter plasma concentration controlled study of the safety and efficacy of oral mycophenolate mofetil for the prevention of acute rejection after kidney transplantation. Transplantation. 1999;68(2):261-6. [pmid: 10440399].
13 Atcheson BA, Taylor PJ, Mudge DW, et al. Mycophenolic acid pharmacokinetics and related outcomes early after renal transplant. Br J Clin Pharmacol. 2005;59(3):271-80. [pmid: 15752372]. [pmcid: 1884792].
14 Borrows R, Chusney G, Loucaidou M, et al. Mycophenolic acid 12-h trough level monitoring in renal transplantation: association with acute rejection and toxicity. Am J Transplant. 2006;6(1):121-8. [pmid: 16433766].
15 Kuypers DR, Vanrenterghem Y, Squifflet JP, et al. Twelve-month evaluation of the clinical pharmacokinetics of total and free mycophenolic acid and its glucuronide metabolites in renal allograft recipients on low dose tacrolimus in combination with mycophenolate mofetil. Ther Drug Monit. 2003;25(5):609-22. [pmid: 14508385].
16 Maes BD, Dalle I, Geboes K, et al. Erosive enterocolitis in mycophenolate mofetil-treated renal-transplant recipients with persistent afebrile diarrhea. Transplantation. 2003;75(5):665-72. [pmid: 12640307].
17 Weber LT, Shipkova M, Armstrong VW, et al. The pharmacokinetic-pharmacodynamic relationship for total and free mycophenolic Acid in pediatric renal transplant recipients: a report of the german study group on mycophenolate mofetil therapy. J Am Soc Nephrol. 2002;13(3):759-68. [pmid: 11856782].
18 Cattaneo D, Gaspari F, Ferrari S, et al. Pharmacokinetics help optimizing mycophenolate mofetil dosing in kidney transplant patients. Clin Transplant. 2001;15(6):402-9. [pmid: 11737117].
19 DeNofrio D, Loh E, Kao A, et al. Mycophenolic acid concentrations are associated with cardiac allograft rejection. J Heart Lung Transplant. 2000;19(11):1071-6. [pmid: 11077224].
20 Shaw LM, Korecka M, Aradhye S, et al. Mycophenolic acid area under the curve values in African American and Caucasian renal transplant patients are comparable. J Clin Pharmacol. 2000;40(6):624-33. [pmid: 10868313].
21 Kaplan B, Meier-Kriesche HU, Friedman G, et al. The effect of renal insufficiency on mycophenolic acid protein binding. J Clin Pharmacol. 1999;39(7):715-20. [pmid: 10392326].
22 Merkel U, Lindner S, Vollandt R, et al. Trough levels of mycophenolic acid and its glucuronidated metabolite in renal transplant recipients. Int J Clin Pharmacol Ther. 2005;43(8):379-88. [pmid: 16119513].
23 Bunchman T, Navarro M, Broyer M, et al. The use of mycophenolate mofetil suspension in pediatric renal allograft recipients. Pediatr Nephrol. 2001;16(12):978-84. [pmid: 11793083].
24 Tsaroucha AK, Zucker K, Esquenazi V, et al. Levels of mycophenolic acid and its glucuronide derivative in the plasma of liver, small bowel and kidney transplant patients receiving tacrolimus and cellcept combination therapy. Transpl Immunol. 2000;8(2):143-6. [pmid: 11005321].
25 Behrend M, Lueck R, Pichlmayr R. Mycophenolic acid and mycophenolic acid glucuronide trough levels after renal transplantation. Transplant Proc. 1997;29(7):2936-8. [pmid: 9365620].
26 Weber LT, Shipkova M, Armstrong VW, et al. Comparison of the Emit immunoassay with HPLC for therapeutic drug monitoring of mycophenolic acid in pediatric renal-transplant recipients on mycophenolate mofetil therapy. Clin Chem. 2002;48(3):517-25. [pmid: 11861442].
27 Armstrong VW, Shipkova M, Schutz E, et al. Monitoring of mycophenolic acid in pediatric renal transplant recipients. Transplant Proc. 2001;33(12):1040-3. [pmid: 11267182].
28 Hazzan M, Labalette M, Copin MC, et al. Predictive factors of acute rejection after early cyclosporine withdrawal in renal transplant recipients who receive mycophenolate mofetil: results from a prospective, randomized trial. J Am Soc Nephrol. 2005;16(8):2509-16. [pmid: 15987748].
29 Lu XY, Huang HF, Sheng-Tu JZ, et al. Pharmacokinetics of mycophenolic acid in Chinese kidney transplant patients. J Zhejiang Univ 2005;Science B(9):885–91.
30 Satoh S, Tada H, Murakami M, et al. Circadian pharmacokinetics of mycophenolic Acid and implication of genetic polymorphisms for early clinical events in renal transplant recipients. Transplantation. 2006;82(4):486-93. [pmid: 16926592].
31 Takahashi K, Ochiai T, Uchida K, et al. Pilot study of mycophenolate mofetil (RS-61443) in the prevention of acute rejection following renal transplantation in Japanese patients. RS-61443 Investigation Committee—Japan. Transplant Proc. 1995;27(1):1421-4. [pmid: 7878933].
32 Sumethkul V, Na-Bangchang K, Kantachuvesiri S, et al. Standard dose enteric-coated mycophenolate sodium (myfortic) delivers rapid therapeutic mycophenolic acid exposure in kidney transplant recipients. Transplant Proc. 2005;37(2):861-3. [pmid: 15848557].
33 Mourad M, Malaise J, Chaib ED, et al. Pharmacokinetic basis for the efficient and safe use of low-dose mycophenolate mofetil in combination with tacrolimus in kidney transplantation. Clin Chem. 2001;47(7):1241-8. [pmid: 11427455].
34 Reggiani P, Arru M, Regazzi M, et al. A “steroid-free” tacrolimus and low-dose mycophenolate mofetil primary immunosuppression does not prevent early acute rejection after liver transplantation. Transplant Proc. 2005;37(4):1697-9. [pmid: 15919435].
35 Satoh S, Tada H, Murakami M, et al. The influence of mycophenolate mofetil versus azathioprine and mycophenolic acid pharmacokinetics on the incidence of acute rejection and infectious complications after renal transplantation. Transplant Proc. 2005;37(4):1751-3. [pmid: 15919454].
36 Kuypers DR, Claes K, Evenepoel P, et al. Clinical efficacy and toxicity profile of tacrolimus and mycophenolic acid in relation to combined long-term pharmacokinetics in de novo renal allograft recipients. Clin Pharmacol Ther. 2004;75(5):434-47. [pmid: 15116056].
37 Mourad M, Chaib-Eddour D, Malaise J, et al. Analytical and clinical evaluation of the EMIT mycophenolic acid immunoassay in kidney transplantation. Transplant Proc. 2000;32(2):404-6. [pmid: 10715456].
38 Mandla R, Midtvedt K, Line PD, et al. Mycophenolic acid clinical pharmacokinetics influenced by a cyclosporine C2 based immunosuppressive regimen in renal allograft recipients. Transpl Int. 2006;19(1):44-53. [pmid: 16359376].
39 Braun F, Canelo R, Schutz E, et al. How to handle mycophenolate mofetil in combination with tacrolimus?. Transplant Proc. 1998;30(8):4094-5. [pmid: 9865309].
40 Tredger JM, Brown NW, Adams J, et al. Monitoring mycophenolate in liver transplant recipients: toward a therapeutic range. Liver Transpl. 2004;10(4):492-502. [pmid: 15048791].
41 Brusa P, Ceruti M, Casullo R, et al. Pharmacokinetic monitoring of mycophenolate mofetil in kidney transplanted patients. Farmaco. 2000;55(4):270-5. [pmid: 10966158].
42 Yamani MH, Starling RC, Goormastic M, et al. The impact of routine mycophenolate mofetil drug monitoring on the treatment of cardiac allograft rejection. Transplantation. 2000;69(11):2326-30. [pmid: 10868634].
43 Pawinski T, Durlik M, Szlaska I, et al. The weight of pharmacokinetic parameters for mycophenolic acid in prediction of rejection outcome: the receiver operating characteristic curve analysis. Transplant Proc. 2006;38(1):86-9. [pmid: 16504671].
44 Gajarski RJ, Crowley DC, Zamberlan MC, et al. Lack of correlation between MMF dose and MPA level in pediatric and young adult cardiac transplant patients: does the MPA level matter?. Am J Transplant. 2004;4(9):1495-500. [pmid: 15307837].
45 Hesse CJ, Vantrimpont P, Van Riemsdijk-van Overbeeke IC, et al. The value of routine monitoring of mycophenolic acid plasma levels after clinical heart transplantation. Transplant Proc. 2001;33(3):2163-4. [pmid: 11377487].
46 Filler G, Gellermann J, Zimmering M, et al. Effect of adding Mycophenolate mofetil in paediatric renal transplant recipients with chronical cyclosporine nephrotoxicity. Transpl Int. 2000;13(3):201-6. [pmid: 10935703].
47 Krumme B, Wollenberg K, Kirste G, et al. Drug monitoring of mycophenolic acid in the early period after renal transplantation. Transplant Proc. 1998;30(5):1773-4. [pmid: 9723276].
48 Lu YP, Zhu YC, Liang MZ, et al. Therapeutic Drug Monitoring of Mycophenolic Acid Can Be Used as Predictor of Clinical Events for Kidney Transplant Recipients Treated With Mycophenolate Mofetil. Transplant Proc. 2006;38(7):2048-50. [pmid: 16979995].
49 Okamoto M, Wakabayashi Y, Higuchi A, et al. Therapeutic drug monitoring of mycophenolic acid in renal transplant recipients. Transplant Proc. 2005;37(2):859-60. [pmid: 15848556].
50 Kreis H, Cisterne JM, Land W, et al. Sirolimus in association with mycophenolate mofetil induction for the prevention of acute graft rejection in renal allograft recipients. Transplantation. 2000;69(7):1252-60. [pmid: 10798738].
51 Wang X, Tang X, Xu D. Immunosuppressive effect of mycophenolate mofetil with two different dosages in cadaveric renal transplantation: a short study. Transplant Proc. 1998;30(7):3573-4. [pmid: 9838564].
52 Kuypers DR, Claes K, Evenepoel P, et al. Long-term changes in mycophenolic acid exposure in combination with tacrolimus and corticosteroids are dose dependent and not reflected by trough plasma concentration: a prospective study in 100 de novo renal allograft recipients. J Clin Pharmacol. 2003;43(8):866-80. [pmid: 12953344].
53 Barbari A, Stephan A, Masri MA, et al. Mycophenolic acid plasma trough level: correlation with clinical outcome. Exp Clin Transplant. 2005;3(2):355-60. [pmid: 16417443].
54 Kuriata-Kordek M, Boratynska M, Klinger M, et al. The efficacy of mycophenolate mofetil treatment in the prevention of acute renal rejection is related to plasma level of mycophenolic acid. Transplant Proc. 2002;34(7):2985-7. [pmid: 12431678].
55 Dipchand AI, Pietra B, McCrindle BW, et al. Mycophenolic acid levels in pediatric heart transplant recipients receiving mycophenolate mofetil. J Heart Lung Transplant. 2001;20(10):1035-43. [pmid: 11595558].
56 Hubner GI, Eismann R, Sziegoleit W. Relationship between mycophenolate mofetil side effects and mycophenolic acid plasma trough levels in renal transplant patients. Arzneim -Forsch. 2000;50(10):936-40. [pmid: 11105237].
57 Kiberd BA, Lawen J, Fraser AD, et al. Early adequate mycophenolic acid exposure is associated with less rejection in kidney transplantation. Am J Transplant. 2004;4(7):1079-83. [pmid: 15196064].
58 Cantin B, Giannetti N, Parekh H, et al. Mycophenolic acid concentrations in long-term heart transplant patients: relationship with calcineurin antagonists and acute rejection. Clin Transplant. 2002;16(3):196-201. [pmid: 12010143].
59 Pillans PI, Rigby RJ, Kubler P, et al. A retrospective analysis of mycophenolic acid and cyclosporin concentrations with acute rejection in renal transplant recipients. Clin Biochem. 2001;34(1):77-81. [pmid: 11239520].
60 Smak Gregoor PJ, van Gelder T, van Besouw NM, et al. Mycophenolic acid trough levels after kidney transplantation in a cyclosporine-free protocol. Transpl Int. 2000;13(Suppl 1):S333-S335. [pmid: 11112026].
61 Orlando G, Baiocchi L, Cardillo A, et al. Switch to 1.5 grams MMF monotherapy for CNI-related toxicity in liver transplantation is safe and improves renal function, dyslipidemia, and hypertension. Liver Transpl. 2007;13(1):46-54. [pmid: 17154392].
62 Bilbao I, Castells L, Rojas L, et al. Immunosuppression based on mycophenolate mofetil in stable liver transplanted patients. International Immunopharmacology. 2006;6(1314):1977-83. [pmid: 17161351].
63 Weber LT, Hoecker B, Armstrong VW, et al. Validation of an abbreviated pharmacokinetic profile for the estimation of mycophenolic acid exposure in pediatric renal transplant recipients. Ther Drug Monit. 2006;28(5):623-31. [pmid: 17038876].
64 Pawinski T, Durlik M, Szlaska I, et al. Comparison of mycophenolic acid pharmacokinetic parameters in kidney transplant patients within the first 3 months post-transplant. J Clin Pharm Ther. 2006;31(1):27-34. [pmid: 16476117].
65 Mudge DW, Atcheson B, Taylor PJ, et al. The effect of oral iron admiinistration on mycophenolate mofetil absorption in renal transplant recipients: a randomized, controlled trial. Transplantation. 2004;77(2):206-9. [pmid: 14742982].
66 Brunet M, Cirera I, Martorell J, et al. Sequential determination of pharmacokinetics and pharmacodynamics of mycophenolic acid in liver transplant patients treated with mycophenolate mofetil. Transplantation. 2006;81(4):541-6. [pmid: 16495801].
67 Mourad M, Malaise J, Chaib ED, et al. Correlation of mycophenolic acid pharmacokinetic parameters with side effects in kidney transplant patients treated with mycophenolate mofetil. Clin Chem. 2001;47(1):88-94. [pmid: 11148182].
68 Smak Gregoor PJ, van Gelder T, van Besouw NM, et al. Randomized study on the conversion of treatment with cyclosporine to azathioprine or mycophenolate mofetil followed by dose reduction. Transplantation. 2000;70(1):143-8. [pmid: 10919591].
69 Borrows R, Chusney G, James A, et al. Determinants of mycophenolic acid levels after renal transplantation. Ther Drug Monit. 2005;27(4):442-50. [pmid: 16044100].
70 Zakliczynski M, Szewczyk M, Zakliczynska H, et al. Clinical application of monitoring mycophenolic acid trough concentration in heart transplant recipients—single center's experience. Ann Transplant. 2005;10(2):38-45. [pmid: 16218032].
71 Grasser B, Iberer F, Schaffellner S, et al. Trough level-guided mycophenolate mofetil rejection prophylaxis in liver transplantation. Transplant Proc. 2001;33(3):2154-6. [pmid: 11377484].
72 van Besouw NM, Van Der Mast BJ, Smak Gregoor PJ, et al. Effect of mycophenolate mofetil on erythropoiesis in stable renal transplant patients is correlated with mycophenolic acid trough levels. Nephrol Dial Transplant. 1999;14(11):2710-3. [pmid: 10534517].
73 Filler G, Lampe D, Mai I, et al. Dosing of MMF in combination with tacrolimus for steroid-resistant vascular rejection in pediatric renal allografts. Transpl Int. 1998;11(Suppl 1):S82-S85. [pmid: 9664950].
74 Smak Gregoor PJ, Hesse CJ, van Gelder T, et al. Relation of mycophenolic acid trough levels and adverse events in kidney allograft recipients. Transplant Proc. 1998;30(4):1192-3. [pmid: 9636482].
75 Deierhoi MH, Kauffman RS, Hudson SL, et al. Experience with Mycophenolate mofetil (RS61443) in renal transplantation at a single center. Ann Surg. 1993;217(5):476-84. [pmid: 8489310]. [pmcid: 1242825].
76 Sugioka N, Sasaki T, Kokuhu T, et al. Clinical pharmacokinetics of mycophenolate mofetil in Japanese renal transplant recipients: A retrospective cohort study in a single center. Biol Pharm Bull. 2006;29(10):2099-105. [pmid: 17015958].
77 Heller T, van Gelder T, Budde K, et al. Plasma concentrations of mycophenolic acid acyl glucuronide are not associated with diarrhea in renal transplant recipients. Am J Transplant. 2007;7(7):1822-31. [pmid: 17532750].
78 Wolfe EJ, Mathur V, Tomlanovich S, et al. Pharmacokinetics of mycophenolate mofetil and intravenous ganciclovir alone and in combination in renal transplant recipients. Pharmacotherapy. 1997;17(3):591-8. [pmid: 9165564].
79 Naesens M, Kuypers DRJ, Verbeke K, et al. Multidrug resistance protein 2 genetic polymorphisms influence mycophenolic acid exposure in renal allograft recipients. Transplantation. 2006;82(8):1074-84. [pmid: 17060857].
80 Staatz CE, Tett SE. Clinical pharmacokinetics and pharmacodynamics of mycophenolate in solid organ transplant recipients. Clin Pharmacokinet. 2007;46(1):13-58. [pmid: 17201457].
81 Johnson PM, Gallinger S, McLeod RS. Surveillance colonoscopy in individuals at risk for hereditary nonpolyposis colorectal cancer: an evidence-based review. Diseases of the Colon & Rectum. 2006;49(1):80-93. [pmid: 16284887].
82 Bullingham RE, Nicholls AJ, Kamm BR. Clinical pharmacokinetics of mycophenolate mofetil. Clin Pharmacokinet. 1998;34(6):429-55. [pmid: 9646007].
83 Division of Transplantation - Health Resources and Services Administration. 2006 Annual Report of the U.S. Organ Procurement and Transplantation Network and the Scientific Registry of Transplant Recipients: Transplant Data 1996-2005. Rockville, MD: Health Resources and Services Administration, Healthcare Systems Bureau, Division of Transplantation; 2006.
84 Geibel J, Longo W. Ethical tensions in solid organ transplantation: The price of success. World J Gastroenterol. 2006;12(20):3259-64. [pmid: 16718849].
85 European Mycophenolate Mofetil Cooperative Study Group. Placebo-controlled study of mycophenolate mofetil combined with cyclosporin and corticosteroids for prevention of acute rejection. European Mycophenolate Mofetil Cooperative Study Group. Lancet. 1995;345(8961):1321-5. [pmid: 7752752].
86 Sollinger HW. Mycophenolate mofetil for the prevention of acute rejection in primary cadaveric renal allograft recipients. U.S. Renal Transplant Mycophenolate Mofetil Study Group. Transplantation. 1995;60(3):225-32. [pmid: 7645033].
87 Tricontinental Mycophenolate Mofetil Renal Transplantation Study Group. A blinded, randomized clinical trial of mycophenolate mofetil for the prevention of acute rejection in cadaveric renal transplantation. The Tricontinental Mycophenolate Mofetil Renal Transplantation Study Group. Transplantation. 1996;61(7):1029-37. [pmid: 8623181].
88 Wiesner R, Rabkin J, Klintmalm G, et al. A randomized double-blind comparative study of mycophenolate mofetil and azathioprine in combination with cyclosporine and corticosteroids in primary liver transplant recipients. Liver Transpl. 2001;7(5):442-50. [pmid: 11349266].
89 Kobashigawa J, Miller L, Renlund D, et al. A randomized active-controlled trial of mycophenolate mofetil in heart transplant recipients. Mycophenolate Mofetil Investigators. Transplantation. 1998;66(4):507-15. [pmid: 9734496].
90 European Mycophenolate Mofetil Cooperative Study Group. Mycophenolate mofetil in renal transplantation: 3-year results from the placebo-controlled trial. European Mycophenolate Mofetil Cooperative Study Group. Transplantation. 1999;68(3):391-6. [pmid: 10459543].
91 Mathew TH. A blinded, long-term, randomized multicenter study of mycophenolate mofetil in cadaveric renal transplantation: results at three years. Tricontinental Mycophenolate Mofetil Renal Transplantation Study Group.[erratum appears in Transplantation 1998 Sep 27;66(6):817]. Transplantation. 1998;65(11):1450-4. [pmid: 9645801].
92 Eisen HJ, Kobashigawa J, Keogh A, et al. Three-year results of a randomized, double-blind, controlled trial of mycophenolate mofetil versus azathioprine in cardiac transplant recipients. J Heart Lung Transplant. 2005;24(5):517-25. [pmid: 15896747].
93 Salvadori M, Holzer H, de Mattos A, et al. Enteric-coated mycophenolate sodium is therapeutically equivalent to mycophenolate mofetil in de novo renal transplant patients. Am J Transplant. 2004;4(2):231-6. [pmid: 14974944].
94 Budde K, Curtis J, Knoll G, et al. Enteric-coated mycophenolate sodium can be safely administered in maintenance renal transplant patients: results of a 1-year study. Am J Transplant. 2004;4(2):237-43. [pmid: 14974945].
95 Kobashigawa JA, Renlund DG, Gerosa G, et al. Similar efficacy and safety of enteric-coated mycophenolate sodium (EC-MPS, myfortic) compared with mycophenolate mofetil (MMF) in de novo heart transplant recipients: results of a 12-month, single-blind, randomized, parallel-group, multicenter study. J Heart Lung Transplant. 2006;25(8):935-41. [pmid: 16890114].
96 Drugsite Trust. Myfortic^®: Consumer Drug Information^. Available at: http://www.drugs.com/mtm/myfortic.html: Accessed May 24, 2007.
97 American Association for Clinical Chemistry. Lab Tests Online: Therapeutic Drug Monitoring. Available at: http://www.labtestsonline.org/understanding/analytes/thdm/glance.html: Accessed on May 22, 2007.
98 Oellerich M, Armstrong VW. The role of therapeutic drug monitoring in individualizing immunosuppressive drug therapy: recent developments. Ther Drug Monit. 2006;28(6):720-5. [pmid: 17164686].
99 Oellerich M, Shipkova M, Schutz E, et al. Pharmacokinetic and metabolic investigations of mycophenolic acid in pediatric patients after renal transplantation: implications for therapeutic drug monitoring. German Study Group on Mycophenolate Mofetil Therapy in Pediatric Renal Transplant Recipients.[erratum appears in Ther Drug Monit 2000 Aug;22(4):500]. Ther Drug Monit. 2000;22(1):20-6. [pmid: 10688252].
100 Drummond MF, Sculpher MJ, Torrance GW, et al. Methods for the economic evaluation of health care programmes. Third Edition. Oxford: Oxford University Press; 2005.
101 Sanderson S, Tatt ID, Higgins JP. Tools for assessing quality and susceptibility to bias in observational studies in epidemiology: a systematic review and annotated bibliography. Int J Epidemiol. 2007;36(3):666-76. [pmid: 17470488].
102 Lohr KN. Rating the strength of scientific evidence: relevance for quality improvement programs. Int J Qual Health Care. 2004;16(1):9-18. [pmid: 15020556].
103 Barbari AG, Masri MA, Stephan AG, et al. Cyclosporine lymphocyte maximum level: a new alternative for cyclosporine monitoring in kidney transplantation. Exp Clin Transplant. 2005;3(1):293-300. [pmid: 15989673].
104 Pape L, Ehrich JH, Offner G. Long-term follow-up of pediatric transplant recipients: mycophenolic acid trough levels are not a good indicator for long-term graft function. Clin Transplant. 2004;18(5):576-9. [pmid: 15344963].
105 Wollenberg K, Krumme B, Schollmeyer P, et al. Pharmacokinetics of mycophenolic acid after renal transplantation. Transplant Proc. 1998;30(5):2237-9. [pmid: 9723455].
106 Brunet M, Martorell J, Oppenheimer F, et al. Pharmacokinetics and pharmacodynamics of mycophenolic acid in stable renal transplant recipients treated with low doses of mycophenolate mofetil. Transpl Int. 2000;13(Suppl 1):S301-S305. [pmid: 11112019].
107 Ringe B, Braun F, Schutz E, et al. A novel management strategy of steroid-free immunosuppression after liver transplantation: efficacy and safety of tacrolimus and mycophenolate mofetil. Transplantation. 2001;71(4):508-15. [pmid: 11258429].
108 Naito T, Shinno K, Maeda T, et al. Effects of calcineurin inhibitors on pharmacokinetics of mycophenolic acid and its glucuronide metabolite during the maintenance period following renal transplantation. Biol Pharm Bull. 2006;29(2):275-80. [pmid: 16462031].
109 Gonzalez-Roncero FM, Gentil MA, Brunet M, et al. Pharmacokinetics of mycophenolate mofetil in kidney transplant patients with renal insufficiency. Transplant Proc. 2005;37(9):3749-51. [pmid: 16386526].
110 Weber LT, Lamersdorf T, Shipkova M, et al. Area under the plasma concentration-time curve for total, but not for free, mycophenolic acid increases in the stable phase after renal transplantation: a longitudinal study in pediatric patients. German Study Group on Mycophenolate Mofetil Therapy in Pediatric Renal Transplant Recipients. Ther Drug Monit. 1999;21(5):498-506. [pmid: 10519445].
111 Johnson AG, Rigby RJ, Taylor PJ, et al. The kinetics of mycophenolic acid and its glucuronide metabolite in adult kidney transplant recipients. Clin Pharmacol Ther. 1999;66(5):492-500. [pmid: 10579476].
112 Weber LT, Shipkova M, Lamersdorf T, et al. Pharmacokinetics of mycophenolic acid (MPA) and determinants of MPA free fraction in pediatric and adult renal transplant recipients. German Study group on Mycophenolate Mofetil Therapy in Pediatric Renal Transplant Recipients. J Am Soc Nephrol. 1998;9(8):1511-20. [pmid: 9697675].
113 Shaw LM, Mick R, Nowak I, et al. Pharmacokinetics of mycophenolic acid in renal transplant patients with delayed graft function. J Clin Pharmacol. 1998;38(3):268-75. [pmid: 9549665].
114 Yatscoff RW, Aspeslet LJ. The monitoring of immunosuppressive drugs: a pharmacodynamic approach. Ther Drug Monit. 1998;20(5):459-63. [pmid: 9780118].
115 Morgera S, Budde K, Lampe D, et al. Mycophenolate mofetil pharmacokinetics in renal transplant recipients on peritoneal dialysis. Transpl Int. 1998;11(1):53-7. [pmid: 9503555].
116 Morgera S, Neumayer HH, Fritsche L, et al. Pharmacokinetics of mycophenolate mofetil in renal transplant recipients on peritoneal dialysis. Int J Clin Pharmacol Ther. 1998;36(3):159-63. [pmid: 9562232].
117 Jain A, Kashyap R, Dodson F, et al. A prospective randomized trial of tacrolimus and prednisone versus tacrolimus, prednisone and mycophenolate mofetil in primary adult liver transplantation: a single center report. Transplantation. 2001;72(6):1091-7. [pmid: 11579306].
118 Staskewitz A, Kirste G, Tonshoff B, et al. Mycophenolate mofetil in pediatric renal transplantation without induction therapy: results after 12 months of treatment. German Pediatric Renal Transplantation Study Group. Transplantation. 2001;71(5):638-44. [pmid: 11292293].
119 Shipkova M, Schutz E, Armstrong VW, et al. Overestimation of mycophenolic acid by EMIT correlates with MPA metabolite. Transplant Proc. 1999;31(12):1135-7. [pmid: 10083508].
120 Lu YP, Lin B, Liang MZ, et al. Correlation of mycophenolic acid pharmacokinetic parameters with side effects in Chinese kidney transplant recipients treated with mycophenolate mofetil. Transplant Proc. 2004;36(7):2079-81. [pmid: 15518752].
121 Ulinski T, Perrin L, Morris M, et al. Autoimmune polyendocrinopathy-candidiasis-ectodermal dystrophy syndrome with renal failure: impact of posttransplant immunosuppression on disease activity. J Clin Endocrinol Metab. 2006;91(1):192-5. [pmid: 16263818].
122 Wang CX, Meng FH, Chen LZ, et al. Population Pharmacokinetics of Mycophenolic Acid in Senile Chinese Kidney Transplant Recipients. Transplant Proc. 2007;39(5):1392-5. [pmid: 17580146].
123 Johnson HJ, Swan SK, Heim-Duthoy KL, et al. The pharmacokinetics of a single oral dose of mycophenolate mofetil in patients with varying degrees of renal function. Clin Pharmacol Ther. 1998;63(5):512-8. [pmid: 9630824].
124 Bloom R, Naraghi R, Cibrik D, et al. OPTICEPT trial: Interm results of 6-month efficacy and safety of monitored mycophemolate mofetil (MMF) in combination with CNI in renal transplantation. Am J Transplant. 2006;6(s2):344.
125 Meier-Kriesche HU, Gaston R, Bloom R, et al. Opticept trial: Interim analysis of renal function after 12 months of monitored myeophenolate mofetil in combination with CNI in renal transplantation. Am J Transplant. 2007;7(Suppl 2):439.
126 Gaston R, Shah T, Bloom R, et al. Opticept trial: interim results of 12-month efficacy and safety of monitored mycophenolate mofetil (MMF) in combination with CNI in renal transplantation. Am J Transplant. 2007;7(Suppl 2 1163):445.
127 Heller T, Armstrong V, Brandhorst G, et al. Plasma concentrations of myocophenolic acid acylglucuronide related to diarrhoea. Interm results from the FDCC study. Am J Transplant. 2006;6(s2):344-5.
128 van Gelder T. The effects of delayed graft function on mycophenolate mofetil pharmacokinetics. Am J Transplant. 2007;7(Suppl 2):162.
129 van Agteren M, van Gelder T. Polymorphism in the ABCB1 (MDR1) gene do not explain the inter-individual variability in mycophenolate mofetil pharmacokinetics. Am J Transplant. 2007;7(Suppl 2):535.
130 Budde K, Tedesco-Silva H, Pestana JM, et al. Enteric-coated mycophenolate sodium provides higher mycophenolic acid predose levels compared with mycophenolate mofetil: implications for therapeutic drug monitoring. Ther Drug Monit. 2007;29(3):381-4. [pmid: 17529899].
131 West-Thielke P, Kaplan B. Therapeutic monitoring of mycophenolic Acid: is there clinical utility?. Am J Transplant. 2007;7(11):2441-2. [pmid: 17868068].