# Acknowledgments

We thank the representatives of our partner organization, the American Association for Clinical Chemistry, Dr. Susan Maynard and Dr. Robert Christenson. We are grateful to members of the technical expert panel who were instrumental in developing the questions and defining the scope of this review: Dr. Klemens Budde, Dr. Guido Filler, Dr. Atholl Johnston, Dr. Les Shaw, and Dr. Maria Shipkova.

Our thanks go to librarian Maureen Rice for her thorough management of the search terms and methodology. We would like to thank the following people who helped with the data abstraction for this review: Connie Freeborn, Rob Stevens, Carolina Ruiz Culebro, Alok Gupta, and Paula Robinson.

Our editorial staff, Cecile Royer, Roxanne Cheeseman, and Sarah Smith, have provided invaluable input into this document.