# Results

## Literature Review and Screening

The literature search yielded 11,642 citations. In total, 1,147 citations (96 percent) were excluded from further review following initial title and abstract screening; 495 citations proceeded to full text screening. Of these 495 citations, 406 (82 percent) were excluded from further review and 89 (18 percent) advanced to the data abstraction phase. At this phase, the 89 studies were slotted according to the key question or questions to which they applied. Three studies^103^–^105^ were not relevant for any of the review questions. Figure 3 depicts the flow of studies through the screening process. As well, the figure shows the reasons for study exclusion. The remainder of this chapter contains sections describing the evidence for the key questions and a quality assessment of the studies.

Figure 3. Flow diagram showing the number of citations processed at each level of the screening process

## Key Questions

### Question 1. What is the Evidence That Monitoring Mycophenolic Acid in Patients who Receive a Solid Organ Transplant Results in a Lower Incidence of Transplant Rejections and Adverse events Compared to Patients who are not Monitored?

Only three studies (four reports)^7^–^10^ contained one group of patients who were monitored and one group of patients who were not monitored. The first study was published by Meiser et al. in two companion papers with identical results.^7,8^ The investigators consecutively enrolled 15 adult, orthotopic heart transplant patients into a study of fixed dose MMF (Mycophenolate Mofetil) (2 g daily) and tacrolimus (group 1). A further 30 patients with the same characteristics were subsequently enrolled to receive MMF and tacrolimus, with MMF dose adjusted according to plasma predose concentration (group 2). Target plasma predose concentrations were set within a range of 2.5 to 4.5 μg/mL. Mean lengths of followup were 696 days (group 1) and 436 days (group 2). Five group 1 patients remained rejection free over the course of followup; 27 group 2 patients also remained rejection free. Plasma MPA (Mycophenolic Acid) predose concentrations were measured retrospectively in group 1 patients and an inverse association was found between mean plasma MPA and the number of rejection episodes per patient: 0 rejections (3.6 μg/mL); one to two rejections (2.2 μg/mL); three rejections (1.4 μg/mL). For group 2 patients, the authors report only the MPA plasma concentrations for the three patients who suffered rejection (1 rejection episode per patient): 0.7, 1.3, and 0.9 μg/mL. Diarrhea or vomiting were reported in six group 1 patients and nine group 2 patients; cytomegalovirus (CMV) was reported in three group 1 patients and four group 2 patients. The authors do not provide p-values or confidence intervals for any inter or intra-group comparisons.

Flechner et al.^9^ conducted a similar sequential allocation study by recruiting one group (n=160) of kidney transplant recipients who received a fixed dose of 2 g MMF daily and a starting dose of 5 g p.o. sirolimus. After this group was recruited, the investigators recruited another group (n=100) who received 1 g MMF daily (sirolimus regimen unchanged relative to 2 g group). Dosage in the 1 g group was adjusted to keep MPA C_0_ concentrations between 1.8 and 4.0 μg/mL.

After six months of followup, there were no differences (p>0.05) between groups in biopsy confirmed acute rejections (8.8 percent [2 g] versus 13.0 percent [1 g]) or mean serum creatinine concentrations (1.41 mg/dL [2 g] versus 1.47 mg/dL [1 g]). There were also no differences in the incidence of CMV or Polyoma viral infections. However, the incidence of some gastrointestinal adverse events was lower in the 1 g group: nausea, vomiting, or dyspepsia (8.0 percent versus 20.6 percent; p=0.007); abdominal pain (4.0 percent versus 10.6 percent; p=0.05); diarrhea (20.0 percent versus 34.3 percent; p=0.01).

The third study,^10^ which was published online in October 2007, was a 12 month RCT comparing adult kidney transplant patients in France. Patients received a quadruple immunosuppressive regime that included randomization to fixed-dose or concentration-controlled MMF. Persons in both groups received 2 g MMF daily for seven days, after which the fixed-dose group could receive dose adjustments based on physician experience. In the concentration-controlled group, a three-point, limited AUC (area under the curve) sampling strategy (20, 60, and 180 minutes post-MMF administration) was calculated using Bayesian estimates to achieve an MPA target dose of 40 mg h/L. MPA was measured with the HPLC assay at days 7 and 14 post-transplant, as well as at months 1, 3, 6, and 12. The primary endpoint was treatment failure, which was a composite endpoint consisting of death, graft loss, acute rejection (renal biopsy or Banff classification), or MMF discontinuation. The primary analysis was an intent-to-treat analysis consisting of 65 patients in each group. There were more treatment failures in the fixed-dose group (n=31; 47.7 percent) than in the concentration-controlled group (n=19; 29.2 percent) (p=0.03). The principal component of these failures was the difference in any type of acute rejection (fixed-dose: n=20 rejections; concentration-controlled: n=8 rejections [p=0.01]). The remaining components of the composite outcome were not statistically significantly different at the 5 percent level. Adverse events tended to be higher in the concentration-controlled group, although the only statistically significant difference (p<0.05) was observed in the case of herpes (eight events in the concentration-controlled group; one event in the fixed-dose group).

### Question 2. Does the Incidence Differ by any of the Following?

#### 2a: MPA Dose and Dose Frequency

The association between dosage and incidence of transplant rejections and adverse events has been described in 41 articles (38 separate studies) of patients who received a solid organ transplant (See Evidence Table 1, Appendix C^*^).^7,^,^8,^,^11,^,^12,14^–^16,^,^18,^,^21,^,^22,^,^24,^,^25,^,^27,^,^28,^,^30,^,^31,^,^33,^,^35,^,^36,39^–^42,^,^44,51^–^53,^,^56,59^–^62,^,^67,^,^69,^,^72,^,^73,75^–^77,^,^106,107^ Of the 41 articles, one^7^ was described in a duplicate report,^8^ two others reported on the same study (i.e., study design and patient population) yet contained different analyses,^11,12^ and another study reported with two different analyses.^36,52^ Five studies (six articles) were randomized controlled trials,^11,^,^12,^,^25,^,^28,^,^51,75^ two (three articles) were non randomized controlled trials,^7,^,^8,31^ seven (one of which was also described in a separate case series) were prospective cohort studies,^24,^,^35,39^–^41,^,^52,77^ two were case control,^53,106^ two were retrospective cohort studies,^22,42^ and 20 (one of which was already described in a separate prospective cohort study^52^) were case series.^14^–^16,^,^18,^,^21,^,^27,^,^30,^,^33,^,^36,^,^44,^,^56,59^–^62,^,^67,^,^69,^,^72,^,^73,76^

* Appendixes and Evidence Tables for this report are provided electronically at http://www.ahrq.gov/clinic/tp/mpaorgtp.htm

Most studies were in kidney transplant recipients. Liver transplant recipients were studied separately in three studies,^40,^,^61,62^ with kidney transplant recipients in one study,^39^ and kidney and small bowel transplant recipients in another.^24^ Heart transplant recipients were studied in five studies (six reports).^7,^,^8,^,^42,^,^44,^,^45,70^ Pediatric transplant recipients were studied separately in two studies,^27,73^ with young adults in one study,^44^ and adults in one study.^40^ Of the four pediatric studies, two were kidney transplant,^27,73^ one was liver transplant,^40^ and one heart transplant.^44^ Young adults were studied with adults in one kidney transplant study.^41^ All other studies involved persons over 16 years of age. There were no studies comparing dose frequencies.

The results of the studies for Question 2a are shown in Tables 1 to 4. In the following paragraphs, we outline the results of the most important studies that address this issue. A total of 10 studies^11,^,^28,^,^30,^,^31,^,^33,^,^35,^,^36,^,^42,^,^52,53^ examined whether MMF dosage was associated with rejection. Three studies^30,^,^31,35^ found an association and seven did not.^11,^,^28,^,^33,^,^36,^,^42,^,^52,53^ Only one study, an RCT by Hale et al.,^11^ attempted to compare rejection outcomes for subjects with planned dose adjustments based on different target MPA plasma or serum concentrations.

Table 1 Studies showing that rejection is related to MMF dosage

Study | Population | Treatment | Major Findings/ Comments
Satoh^35^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 1.0 – 2.0 g/day | MMF dose per bodyweight was lower in patients with AR than those without AR (25.1 vs. 35.6 mg/kg, p=0.026) but there was no significant difference in MPA AUC_0–12_ in patients with AR compared to those without AR (32.2 vs. 59.5 μg·h/L, p=0.081)
Study design: Prospective Cohort | Age: Mean | Concomitant medications:
Length of followup: 28 days | AZA: 37.9 +/- 11.5y | Tacrolimus
| MMF: 44.3 +/- 11.6y | Methylprednisolone
| | Prednisone
Satoh^30^ 2006 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day | Single dose/bodyweight in patients with and without AR were 12.46 and 16.99 mg/kg, respectively (p=0.024)
Study design: Case series | Age: Mean | Concomitant medications:
Length of followup: NR | 41.2 +/- 2.1y | Tacrolimus
| Range | Methylprednisolone
| 21 – 66y | Corticosteroids
Takahashi^31^ 1995 | Organ: Kidney | Dose: 1000, 2000, or 3000 mg/day | The following percentages of patients did not experience rejection episodes in the 1000 mg, 2000 mg, and 3000 mg MMF dose groups: 25.0%, 55.6%, and 80.0%, respectively (p values not given)
Study design: | Age: Inclusion requirement ≥16y | Concomitant medications:
Non randomized controlled trial | 1000 mg/d: Mean 37.7 ± 6.3 y | Cyclosporine
Length of followup: 12 weeks | 2000 mg/d: Mean 38.5 ± 12.2 y | Steroids (no description)
| 3000 mg/d: Mean 41.0 ± 10.3 y

Abbreviations: AR=Acute rejection, AUC=Area-under-the-concentration-time curve, AZA=Azathioprine, MMF=Mycophenolate Mofetil, MPA=Mycophenolic Acid, NR=Not reported, y=Years

Table 2 Studies showing that rejection is not related to MMF dosage

Study | Population | Treatment | Major Findings/ Comments
Barbari^53^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | There was a poor association between clinical events (primarily rejection, but also lymphocyte counts [an indicator of immune responsiveness]) and MMF dosage or MPA predose concentrations (r=0.0803).
Study design: Case control | Age: Mean 39y | range 1 – 2.5 g/day
Length of followup: NR | Range 20 – 67y | Concomitant medications:
| | Cyclosporine
| | Prednisone
Hale^11^ 1998 | Organ transplanted: Kidney (Renal) | Dose: L: 0.45 g BID then adj I: 0.95 g BID then adjusted H: 1.7 g BID then adjusted | Univariate logistic regression p values between biopsy-proven rejection vs. MPA AUC_0–12,_ MPA C_max_, MPA C0, and MMF dose were: < 0.0001, 0.0008, 0.0049, and 0.0918, respectively (i.e., not significant for MMF dose). In bivariate logistic regression analysis, MPA AUC remains statistically significant, but MPA C_max_, MPA C0, and MMF dose are all not significant.
Study design: RCT | Age: Inclusion requirement > 18 y | Concomitant medications:
Length of followup: 20 weeks | Range: | Cyclosporine
| L: 47.8 +/- 11.5 y, | Corticosteroids
| I: 46.9 +/- 13.8y,
| H: 50.6 +/- 10.5y
Hazzan^28^ 2005 | Organ transplanted: Kidney (Renal) | Dose: CsA group MMF dose = 1.93 +/- 0.2 g/day then withdrawn to 0, MMF group MMF dose = 1.99 +/- 0.1 g/day | No significant difference was observed in MMF dose between patients with AR and those without (2.0 vs. 1.9 g/day).
Study design: RCT | Age: Mean | Concomitant medications:
Length of followup: 1 year | CsA 42.5 +/- 12.1y | Cyclosporine
| MMF 45.1 +/- 11.2y
Kuypers^36^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 0.5 g BID or 1 g BID | Same study subjects as Kuypers^52^
Study design: Case series | Age: Median 51.5y | Concomitant medications: | MMF dose was not significantly different in patients with acute rejection compared with those without (17.6 mg·kg^-1^·day^-1^ vs. 20.9 mg·kg·day, p=0.16).
Length of followup: 12 months | | Tacrolimus
| | Methylprednisolone
| | Daclizumab
Kuypers^52^ 2003 | Organ transplanted: Kidney (Renal) | Dose: 1 g/day or 2 g/day | Same study subjects as Kuypers^36^
Study design: Prospective Cohort | Age: Median 51.5y | Concomitant medications: | The percentage of patients with biopsy-proven acute rejection did not differ between the 1- and 2-g MMF groups. One-year patient and graft survival also was not significantly different between the 1- and 2-g MMF groups.
Length of followup: 12 months | | Cyclosporine
| | Tacrolimus
| | Methylpredisolone
| | 31 patients received daclizumab
Mourad^33^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 500 mg BID + adjustment for side effects | MPA measurements at the time of acute rejection for 3 patients (5.8%) at a fixed dose of 500 mg twice daily were: MPA C0 of 1.86, 1.76, and 3.83 mg/L; MPA AUC_0–12_ of 37.7, 24.9, and 104.9 mg.h/L.
Study design: Case series | Age: Range 32–68y | Concomitant medications:
Length of followup: 3 months | Median 49y | Tacrolimus
| | Corticosteroids
Yamani^42^ 2000 | Organ transplanted: Heart (Cardiac) | Dose: 2 g/day | There was no significant difference in mean MMF dose or mean MMF predose concentrations between samples with and without rejection at any time post transplant.
Study design: Retrospective Cohort | Age: Mean | Concomitant medications:
Length of followup: 179 +/- 52 days | 36 +/- 14y | Cyclosporine
| | Tacrolimus
| | Prednisone

Abbreviations: ADJ=Adjusted, AR=Acute rejection, AUC=Area-under-the-concentration-time curve, BID=Twice Daily, C_0_=Predose Trough Serum or Plasma Concentration, C_max_=Maximum Serum or Plasma Concentration, CsA=Cyclosporin A, H=High, I=Intermediate, L=Low, MMF= Mycophenolate Mofetil, MPA=Mycophenolic Acid, NR=Not Reported, RCT=Randomized Controlled Trial, y=Years

Table 3 Studies showing that adverse events are related to MMF dosage

Study | Population | Treatment | Major Findings/ Comments
Bilbao^62^ 2006 | Organ transplanted: Liver | Dose: Initial dose of 500 mg/12h; reaching dose of 1 g each 12h for 2 weeks. | Dose adjustments were based on tolerability and adverse events and not on predose concentrations although they “tried to avoid concentrations over 4 μg/mL”.
Study design: Case series | Age: Mean 59 ± 6y | Concomitant medications:
Length of followup: mean 39 ± 20 months; range 3 to 72 months | | Cyclosporine (Neoral)
| | Tacrolimus
Borrows^14^ 2006 | Organ transplanted: Kidney (Renal) | Dose: 750mg – 2g/day | In multivariate analysis, total daily MMF dose was significantly associated with anemia and MMF-associated diarrhea (p=0.002 and 0.003, respectively), but not with leucopenia, viral infection or acute rejection.
Study design: Case series | Age: Mean 46 +/- 9y | Concomitant medications:
Length of followup: minimum of 12 months; median 25 months; range 13–38 months | Range 37 – 55y | Tacrolimus
| | Methylprednisolone
| | Prednisone
| | Corticosteroids
| | Ganciclovir (for 3 months)
| | Co-Trimoxazole (for 6 months)
| | Isoniazid and Puridoxine (used in indo-asians and those with previous TB)
| | Basiliximab or Daclizumab (79 patients)
Borrows^69^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 250–1500 mg/day corrected for body weight | A higher MMF dose had been given to patients with MMF-related diarrhea (1750 mg vs. 1371 mg, p=0.007).
Study design: Case series | Age: Mean 46 +/- 9y | Concomitant medications:
Length of followup: 30 months; median 19 months; range 6 – 30 months | Range 37–55y | Tacrolimus
| | Methylprednisolone
| | Prednisone
Deierhoi^75^ 1993 | Organ transplanted: Kidney (Renal) | Dose: Phase I: 1500 – 3000 mg/day Rescue: 2000 mg/day and 3000–3500 mg/day if no response in first week | Three patients (28%) required a dose reduction due to side effects (diarrhea, nausea, elevated liver enzymes) and responded to this dose reduction.
Study design: RCT | Age: Inclusion requirement phase I: older than 18y, Rescue: older than 16y | Concomitant medications:
Length of followup: phase I trial: mean 26 months; range 22 – 28 months; rescue: mean 20 months; range 16 – 24 months | | Phase I:
| | Minnesota antilymphocyte globulin(MALG)
| | Methylprednisolone
| | Cyclosporine
| | Corticosteroids
| | Rescue:
| | Predisone
| | Cyclosporine
| | Minnesota antilymphocyte globulin(MALG)
| | Azathioprine
Hale^11^ 1998 | Organ transplanted: Kidney (Renal) | Dose: L: 0.45 g BID then adj : 0.95 g BID then adj H: 1.7 g BID then adj | The risk of diarrhea and the risk of premature study withdrawal due to adverse events were both significantly related to mean MMFdose.
Study design: RCT | Age: Inclusion requirement > 18y | Concomitant medications:
Length of followup: 20 weeks | Range | Cyclosporine
| L: 47.8 +/- 11.5; | Corticosteroids
| I: 46.9 +/- 13.8;
| H: 50.6 +/- 10.5
Kuypers^15^ 2003 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | MMF doses were reduced by blinded investigators when patients experienced adverse events (leucopenia, GI intolerance, infections).
Study design: Case series | Age: Mean 49.4 +/- 13.1y | Concomitant medications:
Length of followup: 12 months | | Methylprednisolone
| | Tacrolimus
| | Daclizumab
Maes^16^ 2003 | Organ transplanted: Kidney (Renal) | Dose: 1.6 +/- 0.5 g/day, range 1 – 3 g/day | MMF dose reduction was the only effective therapy for a Crohn's disease-like enterocolitis. Thus, MMF (and/or MPA) may be a cause.
Study design: Case series | Age: Mean 46 +/- 15y | Concomitant medications:
Length of followup: 2 years | Range 18 – 70y | Cyclosporine
| | Tacrolimus
| | Methylprednisolone
Merkel^22^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 0.5 – 1.0 g BID | More adverse events occurred in patients treated with MMF 2 g/day vs. 1 g/day (p value not given).
Study design: Retrospective Cohort | Age: Mean 44 +/- 13.6y | Concomitant medications:
Length of followup: 16 months, mean 5.7 months | Range 13 – 63y | Cyclosporine
| | Prednisone
| | Corticosteroids
Mourad^33^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 500 mg BID + adjustment for side effects | MMF dose per body surface area (mg/m^2^) twice daily was significantly higher in 31 patients (samples) who experienced adverse events compared with 47 patients (samples) who did not (294.77 vs. 278.02 mg/m^2^, p=0.02).
Study design: Case series | Age: Range 32–68y | Concomitant medications:
Length of followup: 3 months | Median 49y | Tacrolimus
| | Corticosteroids
van Besouw^72^ 1999 | Organ transplanted: Kidney (Renal) | Dose: 2 g/d - 1 g/day | Although MMF dose reduction from 2 g/day to 1.5 g/day did not increase hemoglobin concentration (p=0.12), after a further dose reduction to 1 g/day, the hemoglobin concentration in 20 out of 26 patients had reached pre-conversion (from CsA to MMF) concentrations (p=0.75). The authors summarized that “Not only the MMF dose but also the mycophenolic acid (MPA) predose concentration correlated with the Hb concentration”.
Study design: Case series | Age: Not reported | Concomitant medications:
Length of followup: 8 months | | Prednisone
van Gelder^12^ 1999 | Organ transplanted: Kidney (Renal) | Dose: L: 16.1 ug hr/ml I: 32.2 ug hr/ml H: 60.6 ug hr/ml | Posthoc analysis showed that only the premature withdrawal due to GI (and not other) adverse events was significantly related to MMF dose. This suggests that high local, non-systemic, drug concentrations, may be responsible for the GI adverse events.
Study design: RCT | Age: Range | Concomitant medications:
Length of followup: 6 months | L: 47.8 +/- 11.5y; I: 46.9 +/- 13.8y; H: 50.6 +/- 10.5y | Cyclosporine
| | Prednisone
| | Corticosteroids

Abbreviations: BID=Twice Daily, CsA=Cyclosporin A, GI=Gastrointestinal, H=High, I=Intermediate, L=Low, MMF=Mycophenolate Mofetil, RCT=Randomized Controlled Trial, y=Years

Table 4 Studies showing that adverse events are not related to MMF dosage

Study | Population | Treatment | Major Findings/ Comments
Barbari^53^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | There was a poor association between clinical events (primarily rejection, but also lymphocyte counts [an indicator of immune responsiveness]) and dosage or predose MPA concentrations
Study design: Case control | Age: Mean 39y | range 1 – 2.5 g/day
Length of followup: NR | Range 20 – 67y | Concomitant medications:
| | Cyclosporine
| | Prednisone
Borrows^14^ 2006 | Organ transplanted: Kidney (Renal) | Dose: 750 mg – 2 g/day | In multivariate analysis, total daily MMF dose was not significantly associated with leucopenia, viral infection or acute rejection, but was significantly associated with anemia and MMF-associated diarrhea (p=0.002 and 0.003, respectively)
Study design: Case series | Age: Mean 46 +/- 9y | Concomitant medications:
Length of followup: 38 months | Range 37 – 55y | Tacrolimus
median 25 months | | Methylprednisolone
range 13–38 months | | Prednisone
| | Corticosteroids
| | Ganciclovir (for 3 months)
| | Co-Trimoxazole (for 6 months_
| | Isoniazid and Puridoxine (used in indo-asians and those with previous TB)
| | Basiliximab or Daclizumab (79 patients)
Heller^77^ 2007 | Organ transplanted: Kidney (Renal) | Dose: Fixed dose group: 1 g BID, Concentration-controlled group: target concentration of 30–60 mg*h/L | Mean MMF daily doses were not significantly different between patients with diarrhea versus those without.
Study design: Prospective cohort | Age: Mean 53.4y | Concomitant medications:
Length of followup: 12 months | | Cyclosporine
| | Tacrolimus
Hubner^56^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 1.0 g BID | No significant difference was found in mean MMF dose between patients with adverse events and those without (1.77 vs. 1.90, p>0.05)
Study design: Case series | Age: Mean 45y | Concomitant medications:
Length of followup: NR | | Cyclosporine A
| | Methylprednisolone
Kaplan^21^ 1999 | Organ transplanted: Kidney (Renal) | Dose: 1.75 +/- 0.3 g/day | No p values were given, but there did not appear to be a relation between MMF dose and adverse events nor between MPA AUC and adverse events
Study design: Case series | Age: Range 46.7 +/- 9.2y for chronic renal subjects, 43.3 +/- 8.6y for renal patients without chronic insufficiency | Concomitant medications: Not reported
Length of followup: >2 weeks
Orlando^61^ 2006 | Organ transplanted: Liver | Dose: 250 mg BID increased weekly by 500 mg to dose of 1500 mg/d | All adverse events occurred at MMF doses of 1.5 g except one case of (leukopenia and thrombocytopenia) which occurred at MMF 1 g.
Study design: Case series | Age: Mean 60.1y | Concomitant medications:
Length of followup: mean 31.5 +/- 6.1 months | Range: 35 – 67y | Cyclosporine
| | Tacrolimus
Satoh^35^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 1.0 – 2 g/day | Neither MMF dose per bodyweight (34.0 vs. 32.8 mg/kg, respectively) nor MPA AUC_0–12_ (61.5 vs. 50.4 μg.h/mL, respectively) were significantly different in patients with viral infections compared to those without
Study design: Prospective Cohort | Age:Mean | Concomitant medications:
Length of followup: 28 days | AZA: 37.9 +/- 11.5y | Tacrolimus
| MMF: 44.3 +/- 11.6y | Methylprednisolone
| | Prednisone
Sugioka^76^ 2006 | Organ transplanted: Kidney (Renal) | Dose: MPA group: 1000 or 1500 mg/day | No significant differences were observed in any pharmacokinetic parameter (AUC_0–9,_ C_max_, T_max_, predose concentration, dose, or dose/kg) between patients with and without adverse events of leucopenia or diarrhea
Study design: Case series | Age: Range | Concomitant medications:
Length of followup: 28 days | MPA group: 7 – 69y | Cyclosporine A
| PSL group: 11 – 66y | Tacrolimus
| | Prednisolone
Takahashi^31^ 1995 | Organ transplanted: Kidney (Renal) | Dose: 1000, 2000, or 3000 mg/day | The incidences of adverse events for the 1000 mg, 2000 mg, and 3000 mg MMF dose groups were: 25%, 10%, and 40%, respectively (p> 0.05)
Study design: Non randomized controlled trial | Age: Inclusion requirement ≥16y | Concomitant medications:
Length of followup: 12 weeks | 1000 mg/d: Mean 37.7 +/- 6.3y | Cyclosporine
| 2000 mg/d: Mean 38.5 +/- 12.2 y | Steroids (no description)
| 3000 mg/d: Mean 41.0 +/- 10.3 y
van Besouw^72^ 1999 | Organ transplanted: Kidney (Renal) | Dose: 2 g/d - 1 g/d | MMF dose reduction from 2 g/day to 1.5 g/day did not increase hemoglobin concentration (p=0.12); however, after a further dose reduction to 1 g/day, the hemoglobin concentration in 20 out of 26 patients had reached pre-conversion (from CsA to MMF 0 concentrations (p=0.75). The authors summarized that “Not only the MMF dose but also the mycophenolic acid (MPA) predose concentration correlated with the Hb concentration”.
Study design: Case series | Age: NR | Concomitant medications: Prednisone
Length of followup: 8 months
Wang^51^ 1998 | Organ transplanted: Kidney (Renal) | Dose: | No significant differences were observed in mean C_max_, C_min_, or AUC_0–12_ for patients in the MMF 1 g BID vs. 0.75 g BID groups. One patient in the MMF
Study design: RCT | Age: Range 35–59y | Group 1. 1.0 g BID | 1 g BID group and no patients in the 0.75 g BID group had an acute rejection epsiode. The authors also reported that “There were no obvious differences on MMF side effects between group 1 and group 2” but no data were given
Length of followup: 3 months | | Group 2. 0.75 g BID
| | Concomitant medications:
| | Cyclosporine
| | Corticosteroids
| | Methylprednisolone
| | Prednisone

Abbreviations: AUC=Area-under-the-concentration-time curve, AZA=Azathioprine, BID=Twice Daily, C_max_=Maximum Serum or Plasma Concentration, C_min_=Minimum Serum or Plasma Concentration, CsA=Cyclosporin A, MMF=Mycophenolate Mofetil, MPA=Mycophenolic Acid, NR= Not Reported, PSL=Prednisolone, RCT=Randomized Controlled Trial, T_max_=Mean Time to Maximum Concentration, y=Years

In the Hale et al. trial kidney transplant recipients were allocated to three pre-defined MPA AUC groups (low: 16.1 μg h/L; intermediate: 32.2 μg h/L; high: 60.6 μg h/L). The incidence of biopsy proven acute rejection was 25.5 percent, 8.5 percent, and 5.8 percent respectively in each of the three groups (p=0.043). Univariate logistic regression p-values between biopsy proven rejection vs. MPA AUC_0–12_, MPA C_max_, MPA C_0_, and MMF dose were < 0.0001, 0.0008, 0.0049, and 0.0918, respectively (not significant for MMF dose). In multivariable logistic regression analysis, MPA AUC remained statistically significant, but MPA C_max_, MPA C_0_ (predose plasma or serum concentration), and MMF dose were all not significant.

There were a total of 20 studies containing evidence about whether MMF dosage was associated with adverse events. Ten (11 reports) showed statistically significant associations^11,^,^12,14^–^16,^,^22,^,^33,^,^62,^,^69,^,^72,75^ and 10 showed no significant associations.^14,^,^21,^,^31,^,^35,^,^51,^,^53,^,^56,^,^61,^,^72,76^ Positive associations were observed in the RCT conducted by Hale et al.^11^ and van Gelder et al.^12^ (two reports using data from the same trial), which was the only study that attempted to compare adverse effect outcomes for subjects with planned dose adjustments based on different target MPA plasma concentrations (low: 16.1 μg h/L; intermediate: 32.2 μg h/L; high: 60.6 μg h/L). The risk of diarrhea and the risk of premature study withdrawal due to adverse events were both significantly associated with mean MMF dose.^11^ Posthoc analysis further showed that only the premature withdrawal due to gastrointestinal (and not other) adverse events was significantly related to MMF dose. This suggests that high local, non systemic, drug concentrations may be responsible for MMF's gastrointestinal adverse events. A case series conducted by Hubner et al.^56^ in kidney transplant recipients reported adverse events for subjects with planned dose adjustments based on MPA predose concentrations and subjects taking MMF without changes based on plasma concentrations. The data were graphically depicted and, as such, no direct comparisons could be made. However, the data did show that there was no significant difference in mean MMF dose between patients with or without adverse events (1.77 g/day versus 1.89 g/day, p>0.05).

#### 2b: Type of MPA (mycophenolate mofetil [CellCept^®^], enteric-coated mycophenolate sodium [Myfortic^®^])

There was no evidence in the included studies to answer this question. ECMPS was used in only one study,^32^ which consisted of 12 kidney transplant recipients who were given 720 mg of the drug twice daily within 48 hours post transplant. All of the other included studies used MMF. No study contained direct comparisons of ECMPS and MMF.

### Question 3a: Does the incidence differ by any of the following?

#### Does the Incidence Differ by Albumin versus MPA?

Twenty two studies included measurements of free MPA or albumin in addition to total MPA (See Evidence Table 1, Appendix C^*^).^13^–^21,^,^38,^,^40,^,^52,^,^53,^,^66,^,^69,^,^79,108^–^113^ There were 12 case series,^14^–^19,^,^21,^,^66,^,^69,^,^110,^,^111,113^ six prospective cohort studies,^13,^,^20,^,^38,^,^40,^,^52,79^ two case control studies,^53,112^ and two non randomized controlled trials.^38,108^ The transplanted organs were livers in two studies,^40,66^ hearts in one study,^19^ and kidneys in the remaining 19 studies. Sample sizes ranged from eight^21,113^ to 210.^40^ Patients were between 0.3^40^ and 77 years old.^38^ The percentage of male study subjects ranged from a low of 38 percent in one study^21^ to a high of 82 percent in another.^19^ Patients were followed up from one^111,113^ to 38 months.^14^ Of these 22 studies, 13 compared total with free MPA or albumin.^13^–^21,^,^109,^,^110,^,^112,113^ Out of these, the eight studies most relevant to Question 3aia associated adverse events or rejection with measurements of free vs. total MPA^13,15^–^20^ or albumin versus total MPA.^14^ See Table 5. All studies except Maes et al.^16^ and Shaw et al.^20^ analyzed rejection outcomes. Rejection of a kidney was biopsy proven whenever possible and scored according to Banff criteria in four studies.^13^–^15,17^ Kidney rejection was not defined by Cattaneo et al.^18^ Rejection of a heart was determined by endomyocardial biopsy according to International Society for Heart and Lung Transplantation criteria.^19^ Maes et al.^16^ looked at orocecal transit time (OCTT) and oroanal transit time (OAT) as measures of motility and intestinal absorption in renal transplant patients with persistent afebrile diarrhea. Kidney function tests were analyzed in relation to MPA PK (pharmacokinetic) parameters in six studies.^13^–^15,^,^17,^,^18,20^

Table 5 Association of MPA monitoring with free vs total MPA and albumin

Study | Associations
Atcheson^13^ 2005 | - Urea, creatinine correlate with free fractions of MPA, MPAG; - Albumin correlate negatively with free fractions of MPA, MPAG; - MPA, fMPA unrelated to rejection; - fMPA AUC (but not total) higher with thrombocytopenia, leukopenia, infection than without
Borrows^14^ 2006 | - MPA concentrations correlate with anemia, leukopenia, diarrhea, viral infections; - MPA concentrations inversely correlate with rejection within 1^st^ month; - hypoalbuminemia, renal impairment correlate with hemotoxicity; - No association with MPA - platelets, bacterial infections; - 1.60 mg/L MPA early post-transplant discriminates rejecters/non-rejecters; - 2.75 mg/L MPA later post-transplant discriminates toxicity/no toxicity.
Cattaneo^18^ 2001 | - Creatinine, creatinine clearance correlates with MPA C_0_ and AUC, renal function better with AUC > 40; - Free fraction MPA, not total, correaltes with RBC and leukocytes; - No difference in rejections between AUC > or < 40
DeNofrio^19^ 2000 | - No difference in MPA C_0_ between rejection grades; - MPA AUC, fMPA AUC smaller in grade 2/3 vs. 0 or 1, no difference free vs. total; - No significant difference MPA C0 between grade 2/3 vs. 0 or 1
Kaplan^21^ 1999 | - Free fraction, fMPA AUC, MPAG, but not MPA AUC increased in renal failure; - Hint at increase of leukopenia (but not other adverse events.) with fMPA
Kuypers^15^ 2003 | - No relation MPA, fMPA, AcMPAG, MPAG - efficacy, adverse events; - Intra-patient correlates AcMPAG, MPAG, AcMPAG/MPA - anemia; - fMPA AUC, free fraction MPA, fMPA inverse correlation with GFR; - AcMPAG AUC negative correlation with creatinine clearance; - (fMPA AUC correlates with MPAG AUC)
Maes^16^ 2003 | - MPA, fMPA inverse correlation with colonic transit time, no difference free and total
Shaw^20^ 2000 | - MPA AUC, fMPA AUC, MPA, MPAG not associated with diarrhea; - fMPA AUC higher in 5 patients with leukopenia and IRF than in 8 IRF patients without leukopenia (not significant); - MPA C_-max_, AUC smaller in IRF vs. non-IRF on day 4, NS on day 90; - MPA clearance higher in IRF vs. non-IRF on day 4, NS on day 90; - No difference free fraction AUC in IRF vs non on days 4 and 90
Weber^17^ 2002 | - MPA AUC associated with rejection risk; 33.8 mg*h/L: 75% sensitivity, 64% specificity; - MPA C_12_ 1.2 mg/L discriminates rejectors early post-tx, 83% sensitivity, 64% specificity; - fMPA AUC, not MPA AUC, associated with leukopenia, infection; - Albumin, GFR correlated with MPA AUC 1 wk post transplant, not later

Abbreviations: AcMPAG=Acyl Glucuronide Metabolite of Mycophenolic Acid AUC=Area-under-the-concentration-time curve, C_0_=Predose Trough Blood Concentation, C_max_=Maximum blood or Plasma Concentration fMPA=Free Mycophenolic Acid, GFR=Glomerular Filtration Rate, IRF=Impaired Renal Function, MPA=Mycophenolic Acid, MPAG=Mycophenolic Acid Glucuronide, NS=Not Significant; RBC=Red Blood Cells

All studies except DeNofrio et al.^19^ had adverse events as outcomes. Adverse events (gastrointestinal, haematological, infectious) were well defined by Borrows et al.,^14^ Atcheson et al.,^13^ and Weber et al.^17^ Gastrointestinal and haematological adverse events were well defined by Kuypers et al.^15^ and Cattaneo et al.^18^ Shaw et al.^20^ had clear definitions of haematological adverse events, but not gastrointestinal adverse events. Albumin in relation to MPA PK parameters was analyzed in five studies.^13,^,^14,^,^17,^,^18,20^ In addition to the eight most relevant studies, five studies compared free and total MPA in relation to kidney function tests or albumin, but not to adverse events or rejection.^21,^,^109,^,^110,^,^112,113^

The remaining nine studies were not directly relevant to the key question. Eight studies related total, but not free MPA or albumin, to an outcome.^40,^,^52,^,^53,^,^66,^,^69,^,^79,^,^108,111^ Another study related free MPA to albumin and renal function and total MPA to adverse events and rejection.^38^

Rejection, adverse events, and free versus total MPA. Nine studies associated free MPA PK parameters or albumin with adverse events or rejection.^13^–^21^ Four of these studies did not find statistically significant associations between free MPA parameters and adverse events or rejection, nor differences in this respect between free and total MPA.^15,19^–^21^ Kuypers et al.^15^ did not find significant associations between free or total MPA C_0_, C_max_ (maximum concentration), or AUC values and rejection or adverse events in inter and intra-patient comparisons (data not shown by authors; p-values only given as not significant). Free median MPA predose concentrations within 19 patients were 27.9 μg/L without anemia and 34.2 μg/L with anemia; total MPA predose concentrations were and 2.61 mg/L without and 2.0 mg/L with anemia. DeNofrio et al.'s study^19^ of heart transplant patients found lower AUCs of total MPA and free MPA (fMPA) in grade 2/3 rejection versus grade 0 or grade 1 rejection (all results significant except the total MPA grade 2/3 versus grade 0 comparison [p<0.08]). However, there were no reported differences for free versus total MPA. Two studies found that five^20^ or four^21^ patients with impaired renal function who developed leukopenia tended to have higher fMPA AUCs than patients who did not develop leukopenia, but the small numbers did not allow statistical conclusions. No comparison to total MPA was made in these cases. Diarrhea in 10 out of 33 patients was not associated with high free or total MPA C_0_ or predose values (data not shown by authors).^20^

Atcheson et al.^13^ found no association between free or total MPA parameters and rejection, gastrointestinal effects, or anemia. On the other hand, the mean fMPA AUC_0–6_ was significantly higher in patients with thrombocytopenia, leucopenia, or infections (1.9 mg h^-1^ l^-1^) than in patients without these outcomes (1.1 mg h^-1^ l^-1^; 95 percent CI for the difference: 0.3 to 1.4; p=0.0043). Total MPA AUC_0–6_ values for these outcomes were not different (p=0.18). Weber et al.^17^ also found that fMPA AUC, but not total MPA AUC, were associated with leukopenia and infections. Similarly, Cattaneo et al.^18^ saw a correlation between the free fraction of MPA (but not total MPA) and lower red blood cell and leukocyte counts. Borrows et al.^14^ did not measure fMPA, but correlated hypoalbuminemia and renal impairment, both known to increase fMPA (see below), with hemotoxicity. Multivariable analysis showed that higher MPA predose concentrations, lower serum albumin, and lower estimated creatinine clearance (eCrCl) were independently associated with a higher probability of anemia (relative risk [RR] for 1 mg/L rise in median MPA concentration in the 30 days before the event: 1.62; 95 percent CI: 1.24 to 2.12; RR for 10 g/L rise in albumin: 0.70; 95 percent CI: 0.40 to 0.87; RR for 10 mL/min rise in eCrCl (estimated creatinine clearance): 0.80; 95 percent CI: 0.67 to 0.91; p<0.001 for all). According to receiver operating curve (ROC) analysis, an MPA predose concentration of 2.60 mg/L and a serum albumin concentration of 29 g/L best discriminated patients with and without anemia.

Maes et al.^16^ studied patients with unexplained enterocolitis and persistent afebrile diarrhea without evidence of infections and found a correlation between oroanal transit time and MPA (r=-0.87; p=0.02) or fMPA (r=-0.88; p=0.02), but no difference between MPA and fMPA (p>0.05). They hypothesized MPA to be causal in this relationship. None of the studies above seemed to have found free MPA PK parameters useful to predict diarrhea or rejection.

Kidney function, albumin, and free MPA. Studies that related kidney function or albumin to free MPA measurements^13,^,^15,^,^20,^,^21,^,^38,^,^109,^,^110,^,^112,113^ generally found that impaired kidney function as well as hypoalbuminemia were associated with increased concentrations or AUCs of fMPA and MPAG but not total MPA. Weber et al.^112^ showed that free, but not total, MPA AUC_0–12_ values were inversely correlated with GFR (Glomerular Filtration Rate) in 18 children and 10 adults (r=- 0.57, p < 0.01 at 1 week; r=-0.41, p < 0.05 at 3 weeks after renal transplantation). In children (36 observations from weeks 1 and 3 combined), the MPA free fraction was inversely correlated with serum albumin (r=-0.54, p<0.01) and GFR (r=-0.60, p<0.001). Forward stepwise regression showed that the free fraction of MPA was significantly related to albumin and GFR (r^2^=0.46). In adults the MPA free fraction was also inversely correlated with GFR (r=-0.70, p<0.005), but not with albumin. Conversely, Johnson et al.,^111^ who did not measure fMPA, found by multiple linear regression in 10 kidney transplant patients that creatinine (p=0.01) and albumin (p=0.03) predicted total MPA AUC_0–12_.

#### Does the Incidence Differ by Genetic Differences or Metabolite Concentrations?

The relationships between genetic polymorphisms, pharmacokinetics of MPA, and health outcomes were examined by two studies.^30,79^ Twenty three studies reported measurement of the major, inactive, phenolic conjugate metabolite mycophenolic acid-7-O-glucuronide (MPAG) (See Evidence Table 1, Appendix C^*^ and Table 6).^15,^,^16,^,^18,20^–^25,^,^32,^,^38,^,^44,^,^58,^,^64,^,^73,108^–^115^ The active acyl glucuronide metabolite of MPA (AcMPAG) was measured in two of the 23 studies.^15,16^ Fourteen studies were case series,^15,^,^16,^,^18,^,^21,^,^30,^,^32,^,^44,^,^58,^,^64,^,^73,^,^110,^,^111,^,^113,116^ six were prospective cohort studies,^20,^,^23,^,^24,^,^79,^,^109,115^ two were non randomized controlled trials,^38,108^ one was a retrospective cohort study,^22^ one was a case control study,^112^ and one was a randomized controlled trial.^25^ Almost all studies dealt only with kidney transplantation, except for two heart transplant studies^44,58^ and one study including liver, small bowel, and kidney recipients.^24^ Samples ranged from five^115,116^ to 95 people.^79^ Ages ranged from 1 month^44^ to 77 years.^38^ Between 20^115,116^ and 73 percent^38,58^ of participants were male and were followed up from 2 days^115,116^ to 3 years.^23^

Table 6 Association of MPA outcomes with metabolites or genes

Study | Associations
Behrend^25^ 1997 | MPA, MPAG - renal function (MPA not correlation., MPAG inverse correlation., data not shown), AE/R (no association., data not shown)
Bunchman^23^ 2001 | MPA, MPAG - AE/R, No associations found, but data not shown
Cantin^58^ 2002 | MPA - rejection
Cattaneo^18^ 2001 | MPA - rejection, kidney function; fMPA, MPA - AE
Filler^73^ 1998 | MPA - diarrhea
Gajarski^44^ 2004 | MPA - rejection
Gonzalez-Roncero ^109^ 2005 | MPA, fMPA, MPAG, C_0_ and AUC - renal function: all higher in renal insufficiency than normal renal function, except MPA AUC
Johnson^111^ 1999 | MPA, MPAG AUC correlation - creatine; MPA AUC correlation - albumin
Kaplan^21^ 1999 | fMPA, MPAG AUC incr. in renal failure vs. function, MPA AUC same
Kuypers^15^ 2003 | MPA, metabolites - AE/R, lab outcomes
| Intra patient:
| No association MPA, fMPA, AcMPAG, MPAG C_0_, C_max_, AUC - rejection, diarrhea, leukopenia
| Higher AcMPAG C_0_, MPAG C_0_, AcMPAG/MPA, but not MPA in anemia (n=19) vs. not
| MPA, fMPA, MPAG, AcMPAG C_max_ or AUC: no difference between anemia (n=29) or leucopenia (n=12) or not
| Inter-patient: No association MPA, fMPA, AcMPAG, MPAG C_0_, C_max_, AUC - rejection, diarrhea, leukopenia, anemia (data not shown); diarrhea, rejection not captured by AUCs, C_max_ (too rare)
| Correlation with GFR:
| MPAG C_0_: r^2^ = -0.791
| MPAG AUC: r^2^ = -0.709
| fMPA C_0_: r^2^ = -0.791
| fMPA AUC: r^2^ = -0.477
| AcMPAG C_0_: r^2^ = -0.781
| AcMPAG AUC: r^2^ = -0.505
| MPA C_0_: r^2^ = 0.399
| MPA AUC: r^2^= -0.039; all p<0.001
Maes^16^ 2003 | MPA, metabolites. - fecal fat loss
| Correlation fecal fat loss MPAG, AcMPAG, probably not MPA
Mandla R ^38^ 2006 | MPA - rejection; fMPA - albumin, kidney function
Merkel U ^22^ 2005 | Linear correlation. MPA C_0_ - creatine, MPAG C_0_ - creatine stronger correlation
| Slight linear correlation MPA - protein, not MPAG - protein
| Elevated transaminases (3 patients): MPA, MPAG concentrations similar to those without elevated transaminases
| Two CMV infections: MPA, MPAG in 1^st^ patient similar to those in patients without CMV; MPA in second (reactivated chronic) CMV patient higher than in first CMV patient
| One diarrhea, no correlation to concentrations
| 4 rejections in 35 patients, 2 MPA concentrations in 2 acute rejections
Mogera^115^ 1998 | MPA, MPAG AUC inverse correlation - GFR
Morgera^116^ 1998 | MPAG AUC inverse correlation. - GFR, no difference for MPA
Naito^108^ 2006 | Positive correlation MPA, MPAG C_0_ - creatine, stronger with CyA than Tac
Naesens^79^ 2006 | MPA - liver and renal function, genes; genes - AE/R (diarrhea)
Pawinski^64^ 2006 | MPA - rejection (ROC), renal function
Satoh^30^ 2006 | MPA - rejection, genes; genes - AE/R (diarrhea)
Shaw^20^ 2000 | MPA, fMPA, MPAG - diarrhea, renal function
| No association MPA, fMPA, MPAG - diarrhea
| MPAG, not MPA C_0_ higher in IRF
Shaw^113^ 1998 | free fraction, MPAG, creatinine decrease with time, MPA increases but cannot be modeled
Sumethku^32^ 2005 | MPA - AE/R
Tsaroucha^24^ 2000 | MPA, MPAG - rejection (no correlation)
Weber^110^ 1999 | fMPA, MPAG AUC - GFR (inverse correlation), MPA AUC increases with time, fMPA, MPAG AUCs consistent
Weber^112^ 1998 | fMPA, MPAG, not MPA inverse correlation with GFR

Abbreviations: AcMPAG=Acyl Glucuronide Metabolite of Mycophenolic Acid, AE=Adverse Events, AE/R=Adverse/Rejection, AUC=Area-under-the-concentration-time curve, C_0_=Predose Trough Serum or Plasma Concentration, C_max_=Maximum Serum or Plasma Concentration, CMV=Cytomegalovirus, CyA=Cyclosporine, fMPA=Free Mycophenolic Acid, GFR=Glomerular Filtration Rate, IRF=Impaired Renal Function, MPA=Mycophenolic Acid, MPAG=Mycophenolic Acid Glucuronide, ROC= Receiver Operating Characteristic, TAC=Tacrolimus

Outcomes described in one of the genetic papers^79^ included diarrhea, leucopenia, and other haematological disorders, as well as biopsy proven acute rejection, all in relation to single nucleotide polymorphisms (SNPs). Liver dysfunction was also described in relation to MPA PK parameters and SNP genotype.^79^ Delayed graft function and hypoalbuminemia were associated with MPA PK parameters. The second genetic study^30^ associated MPA PK parameters and SNPs with acute rejection (classified according to Banff criteria) and diarrhea (undefined) with genotype.

Sixteen out of the 23 studies that measured metabolites compared PK parameters of MPA with those of its metabolites in relation to health outcomes.^15,^,^16,20^–^25,^,^38,^,^108,110^–^115^ Out of these studies, the seven studies most relevant to questions about biological variation associated adverse events or rejection with measurements of MPA versus metabolites.^15,^,^16,^,^20,22^–^25^ Adverse events were described by five studies^15,^,^20,^,^22,^,^23,25^ Merkel et al.^22^ list hemoglobin, elevated transaminases, CMV infection, and diarrhea (all undefined) as adverse drug reactions. Kuypers et al.^15^ reported anemia (hemoglobin < 11 g/dL beyond the first month), leukopenia (white cells < 4 × 109/L) and other less well defined adverse events. Maes et al.^16^ reported fecal fat loss and Bunchman^23^ reported undefined gastrointestinal, haematological, and infectious adverse events. Tsaroucha et al.^24^ described only minor gastrointestinal problems without attempts at correlation to MPA. Shaw et al.^20^ defined leukopenia (whole blood count < 5000), but not gastrointestinal effects. Behrend et al.^25^ did not specify their observed adverse events. A few studies^22,^,^25,117^ did not contain clear definitions of rejections. Others^15,^,^16,23^ used Banff criteria if biopsy was not contraindicated. Shaw et al.^20^ defined rejection as based mostly on creatinine, but didn't relate this outcome to MPA or metabolites, and neither did Maes et al.^16^ Renal function tests or albumin were evaluated in connection with MPA or metabolites in four of the seven studies.^15,^,^20,^,^22,25^ The seven studies of highest relevance were accompanied by nine studies that compared MPA and metabolites related to lab based outcomes, but not to adverse events or rejection.^21,108^–^113,^,^115,116^

The remaining seven less relevant studies did not compare either MPA to metabolites or associate outcomes with metabolites.^18,^,^32,^,^38,^,^44,^,^58,^,^64,73^ They did relate MPA mostly to rejection outcomes.

Pharmacogenetics. Naesens et al.^79^ found that seven days after transplantation, renal allograft recipients (n=9) without the C-24T SNP of the multidrug resistance associated protein 2 (MRP2), but with mild liver dysfunction, had lower MPA exposure compared to MRP2 C-24T non carriers (n=45) without liver dysfunction. Dose corrected MPA C_0_ concentrations were 1.9 ± 1.6 versus 3.8 ± 3.2 mg/L·g (p=0.045) in liver disease versus no liver disease. Dose corrected MPA AUC_0–12_ values were 34.1 ± 16.8 versus 81.8 ± 51.0 mg·h/L·g (p=0.0007). MPA exposure in carriers of the MRP2 C-24T variant were similar with (n=7) or without (n=34) liver dysfunction. In this subgroup, the dose corrected MPA C_0_ concentrations were 3.4 ± 2.5 versus 4.0 ± 2.5 mg/L·g (p > 0.05) in liver disease versus no liver disease. Dose corrected MPA AUC_0–12_ values were 94.4 ± 50.4 versus 79.6 ± 35.4 mg·h/L·g (p=0.0007). The C-3972T variant, in linkage disequilibrium with C-24T, led to similar effects. The C-24T SNP was associated with higher MPA exposure later after transplantation and with more diarrhea within one year after surgery.

Satoh et al.^30^ studied the circadian variation of MPA PK, the association between MPA PK and acute rejection, and the association of several polymorphisms related to the Clock gene, the uridine diphosphoglucuronosyltransferase (UGT) system, cytochrome P450 3A5, and the multidrug resistance 1 (MDR1) C3435T variant, with circadian MPA variation and the incidence of adverse events and rejection. MPA PK was found to vary with the time of the day (daytime AUC > nighttime AUC). MPA PK parameters were lower in patients with acute rejection than in those without, and the MDR1 C3435T genotype was associated with a higher incidence of diarrhea than in patients with the CC genotype (p=0.049). No direct associations between genotype, MPA PK, and outcomes were found.

Rejection, adverse events, and metabolites versus MPA. Seven studies related adverse events or rejection with measurements of MPA versus metabolites.^15,^,^16,^,^20,22^–^25^ Significant associations were found in two studies.^15,16^ Kuypers et al.^15^ reported higher median AcMPAG (0.24 versus 0.12 mg/L, p=0.03), MPAG C_0_ concentrations (62.8 versus 58.3 mg/L, p=0.02), and AcMPAG/MPA ratios (0.10 vs. 0.06, p=0.004), but not higher MPA C_0_ concentrations (2.0 vs. 2.61 mg/L, p>0.05) in patients who experienced anemia compared with times when they did not experience anemia (intra-patient comparison, 19 concentrations). The authors also found lower median MPAG C_0_ concentrations (n=10) at times of a leucopenia episode compared to concentrations at times of no leukopenia (47.2 versus 60.5 mg/L, p=0.04). With these exceptions, inter- and intra-patient comparisons of C_0_ concentrations, AUCs, or C_max_ concentrations of MPA, fMPA, AcMPAG, and MPAG between the presence or absence of acute rejection, diarrhea, leucopenia, and anemia yielded no significant differences.

Maes et al.^16^ found a correlation between the amount of fecal fat loss (a measure of fat malabsorption with steatorrhea) and MPAG concentrations (r=0.9955, p<0.001), as well as AcMPAG concentrations (r=0.90, p=0.015) in five renal allograft recipients with persistent afebrile diarrhea.

Negative results concerning MPA and MPAG concentrations were found in association with the following: elevated transaminases, CMV infections, diarrhea, and rejections;^22^ diarrhea, anemia, leucopenia, sepsis, and rejections (no data shown);^23^ adverse gastrointestinal effects and rejection in liver transplant recipients;^24^ diarrhea;^20^ and unnamed adverse events and rejection (data not shown).^25^

Kidney function, albumin and metabolites versus MPA. Thirteen studies compared MPA and metabolites related to lab based outcomes.^15,20^–^22,^,^25,108^–^113,^,^115,116^ MPAG C_0_ concentrations or AUCs were found in all these studies to significantly increase with decreased kidney function as measured by creatinine concentrations or clearance. MPA C_0_ and AUC results behaved less predictably and could either increase, decrease, or not change with kidney function. In a study of kidney transplant recipients,^109^ MPAG C_0_ and AUC were elevated in renal insufficiency compared to preserved renal function (MPAG C_0_ = 274 ± 114 versus 92.6 ± 36 ug/mL, p<0.001; MPAG AUC = 3527 ± 1130 versus 1550 ± 392 μg·h/mL, p < 0.001). In contrast, MPA C_0_ was elevated (2.12 ± 1.4 versus 1.15 ± 0.6 μg/mL, p=0.037), but MPA AUC was not (48.9 ± 19 versus 47.3 ± 8.8 μg·h/mL, p > 0.05).

Albumin was correlated to MPA, but not to MPAG.^22,111^ Multiple linear regression with adjustment for covariates found that serum albumin in renal allograft recipients positively predicted MPA AUC_0–12_ (p=0.03), but not MPAG AUC_0–12_.^111^

#### Does the Incidence Differ by Assay Method?

Among all the included studies, only two case series^26,27^ involved direct comparisons of different assay methods (See Evidence Table 1, Appendix C^*^). Both case series contained children with transplanted kidneys from the same longitudinal research project.^17,^,^110,^,^112,118^ In one study, by Weber et al.,^26^ 50 patients (31 males) were between 3.2 and 16.0 years old. In the other study, by Armstrong et al.,^27^ the authors did not report the age or sex of their subgroup of 40 patients. Followup was for six months^26^ or 70 days.^27^

Both papers reported the EMIT (Enzyme multiplied immunoassay technique) and HPLC (High performance liquid chromatography) assays to measure total MPA C_0_, C_max_, and AUC_0–12_. Weber et al.^26^ also measured C_12_ (evening predose) and two abbreviated AUCs. Fifteen of the patients in the Weber et al. study had a rejection, 11 of which were biopsy proven (Banff criteria) and four of which were diagnosed on the basis of one or more clinical findings (i.e., body temperature, graft swelling, tenderness, creatinine 20 percent more than baseline value, oliguria). Nine patients in the Armstrong et al. study had acute rejection, which the authors did not define.^27^

Both studies found EMIT and HPLC equally able to discriminate between patients with acute rejections during the first 70 days post transplant. This was true for C_0_ and AUC_0–12_ in the Armstrong et al. study^27^ and for C_0_, C_12_, AUC_0–12_ and the abbreviated AUC estimate AUC_0,75min,4h_ in Weber et al.^26^ Decision concentrations, below which the risk of acute rejection is increased, were higher with EMIT than with HPLC, presumably because of the known cross reactivity of the EMIT assay with the active metabolite AcMPAG.^119^ The cut offs for AUC_0–12_, with a diagnostic sensitivity of 67.7 percent and a diagnostic specificity of 79.4 percent, were 29.5 mg·h/L for HPLC and 36.1 mg·h/L for EMIT.^27^ The other study showed AUC_0–12_ cut offs at 80 percent sensitivity and 57 percent specificity to be 33.8 mg·h/L (HPLC) and 36.1 mg·h/L (EMIT).^26^ Cut offs for C_0_ were 1 mg/L (sensitivity 77.8 percent, specificity 64.5 percent, HPLC) and 1.3 mg/L (EMIT).^27^ Weber et al.^26^ reported a better performance of C_12_ versus C_0_ with cut offs for C_12_ of 1.2 (HPLC) and 1.4 mg/L (EMIT) (sensitivity 80 percent, specificity 60 percent). Areas under the ROC curves for C_0_, C_12_ and AUC_0–12_ ranged from 0.64 (EMIT, AUC, 95 percent confidence interval (CI): 0.45 to 0.84; p=0.04) to 0.70 (HPLC, C_12_, 95 percent CI: 0.53 to 0.87; p=0.01),^26^ or from 0.71 (EMIT, 95 percent CI: 0.51 to 0.91; p=0.020 [AUC]; 0.53 to 0.89; p=0.012 [C_0_]) to 0.73 (HPLC, AUC, 95 percent CI: 0.53 to 0.94; p=0.012).^27^ C_max_ was not able to discriminate rejectors significantly in either study. None of the PK parameters, regardless of assay method, were associated with the incidence of adverse events (diarrhea, anemia, thrombocytopenia, leukopenia, and several viral, fungal and bacterial infections).^26^

HPLC-MS was used so rarely that the performance of this assay method could not be assessed.

### 3b: Does the Incidence Differ by Method of MPA Monitoring (Full AUC or Limited Sampling Strategies [i.e., Predose Concentrations, 2 hour Post Dose Concentrations, Other])?

The association between the method of MPA monitoring and incidence of transplant rejections and adverse events has been described in 71 reports (67 separate studies) of patients who received a solid organ transplant. The characteristics of these studies are shown in Evidence Table 1, Appendix C^*^).^7,^,^8,10^–^22,24^–^77,^,^106,120^ Of the 67 studies, one^7^ was described in a duplicate report,^8^ another was first described partially^120^ and then in full,^48^ two other articles reported on the same study (study design and patient population) yet involved different analyses,^11,12^ and another study reported with two different analyses.^36,52^ Eleven studies (12 articles) were RCTs,^10^–^12,^,^25,^,^28,^,^29,^,^34,^,^50,^,^51,^,^65,^,^68,75^ four (five articles) were non randomized controlled trials,^7,^,^8,^,^31,^,^38,49^ nine (one of which was also described in a separate case series) were prospective cohort studies,^13,^,^20,^,^24,^,^35,39^–^41,^,^52,77^ three were case control,^53,^,^54,106^ three were retrospective cohort studies,^22,^,^42,55^ and 41 (including one^48^ that was also published partially^120^) were case series.^14^–^19,^,^21,^,^26,^,^27,^,^30,^,^32,^,^33,^,^36,^,^37,43^–^48,^,^53,^,^54,56^–^64,^,^66,^,^67,69^–^74,^,^76,106^

Most studies were in kidney transplant recipients. Liver transplant recipients were studied separately in six studies,^34,^,^40,^,^61,^,^62,^,^66,71^ with kidney transplant recipients in one study,^39^ and with kidney and small bowel transplant recipients in one study.^24^ Heart transplant recipients were studied in eight studies, (nine reports).^7,^,^8,^,^19,^,^42,^,^44,^,^45,^,^55,^,^58,121^ Pediatric transplant recipients were studied separately in seven studies,^17,^,^26,^,^27,^,^46,^,^55,^,^63,73^ with young adults in one study,^44^ and with adults in one study.^40^ Of the nine pediatric studies, all involved kidney transplant with the exception of one in liver transplant^40^ and two in heart transplant.^44,55^ Young adults were studied with adults in one kidney transplant study.^41^ All other studies involved persons older than 16 years of age.

Of the RCTs, only one is a head-to-head study of concentration monitoring versus no concentration monitoring^10^ and only two trials (three articles)^11,^,^12,29^ had the primary aim of correlating pharmacokinetic parameters with clinical outcomes. None of the other RCTs were designed with this aim in mind and hence they did not provide direct evidence of the utility of MPA measurements as they related to clinical outcomes.

Method of MPA Monitoring. MPA monitoring took the form of full AUC measurements over a 12 hour period (AUC_0–12_ - seven to 10 plasma or serum samples) in 17 reports.^11,^,^12,^,^17,26^–^30,^,^32,^,^33,^,^35,^,^36,^,^46,^,^52,^,^66,^,^67,106^ One study^37^ used AUCs based on five serum samples. The number of samples was not reported in three studies.^31,^,^34,43^

Single sample limited sampling strategies included predose (i.e., C_0_, C_min_, or C_12_) in 59 studies,^7,^,^8,^,^11,^,^12,14^–^20,^,^22,24^–^28,^,^30,^,^32,^,^33,36^–^42,44^–^50,52^–^62,^,^64,66^–^76,^,^106,120^ 2 hour post dose concentration (C_2_) in two studies,^54,57^ peak (or maximal or C_max_) in 11 studies,^11,^,^17,^,^26,^,^36,^,^43,^,^51,^,^52,^,^54,^,^66,^,^75,76^ C_30min_ in two studies,^33,67^ C_40min_ in three studies,^21,^,^54,66^ and C_60min_ in two studies^33,54^ Three sample limited sampling strategies included AUC based on C_0_, C_0.5_, C_2_^43,^,^63,^,^64,77^ AUC based on C_20min_, C_1_, C_3,_^10^ and AUC based on C_0_, C_75min_, C_4_.^17,26^ Four sample limited sampling strategies included AUC based on C_0_, C_1_, C_2_, C_4_^57^ and AUC based on C_0_, C_1_, C_3_, C_6_.^13,^,^59,65^ The five sample limited sampling strategy included AUC based on C_0_, C_20min_, C_40min_, C_75min_, C_120min_.^17^–^21,26^ The seven sample limited sampling strategy included AUC based on C_0_, C_1_, C_2_, C_3_, C_4_, C_6_, C_9_.^76^ A final strategy was AUC_0–9_ (sampling times not provided).^49^

Rejection. Thirty studies, (32 reports) contained evidence showing that a method of MPA monitoring is associated with incidence of rejection (Tables 7 to 10 ).^7,^,^8,10^–^12,^,^17,^,^19,26^–^33,38^–^49,^,^54,^,^57,^,^59,^,^63,64^ Conversely, 29 studies, (30 reports) contained evidence against such associations (Tables 11 to 14).^11,^,^13,^,^15,^,^17,^,^19,24^–^26,^,^28,34^–^37,^,^42,^,^45,49^–^62,65^

Table 7 Studies showing some relationship between rejection and method of MPA monitoring

Study | Population | Treatment | Major Findings/ Comments
Armstrong^27^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BID | MPA AUC cut off of 29.5 mg.h/L (HPLC) for acute rejection had a diagnostic sensitivity of 66.7% and a diagnostic specificity of 79.4%.
Study design: Case series | Age: Inclusion requirement pediatric | Concomitant medications:
Length of followup: 70 days | Mean NR | Cyclosporine
| | Methylprednisolone
Hale^11^ 1998 | Organ transplanted: Kidney (Renal) | Dose: L: 0.45 g BID then adjust; I: 0.95 g BID then adjust; H: 1.7 g BID then adjust | According to logistic regression analysis, MPA AUC values of 15, 25, and 40 mg.h/L are expected to yield 50%, 75%, and 90% of maximal achievable efficacy (with a 4% change in efficacy for every 1 mg.h/mL change in AUC at the midpoint of the logistic curve). Univariate logistic regression p values between biopsy-proven rejection vs. MPA AUC was < 0.0001. Note that the first 3 assessments were of full 12h AUCs whereas the later 6 assessments were of AUC_0–12_ (as predicted by LSS of C_0_, C_20min_, C_40min_, C_75min_, and C_2h_).
Study design: RCT | Age:Inclusion requirement > 18y Range | Concomitant medications:
Length of followup: 20 weeks | L: 47.8 +/- 11.5y; | Cyclosporine
| I: 46.9 +/- 13.8y; | Corticosteroids
| H: 50.6 +/- 10.5y
Hazzan^28^ 2005 | Organ transplanted: Kidney (Renal) | Dose: CsA group MMF dose = 1.93 +/- 0.2 g/day then withdrawn to 0, MMF group MMF dose = 1.99 +/- 0.1 g/day | MPA AUC (a 50 mg·h/L cut off), but not MPA predose concentration, was associated with risk for AR in multivariate analysis. Authors suggest that this cut off “needs to be confirmed by further investigations”.
Study design: RCT | Age: Mean | Concomitant medications:
Length of followup: 1 year | CsA 42.5 +/- 12.1 | Cyclosporine
| MMF 45.1 +/- 11.2 | Prednisone
Lu^29^ 2005 | Organ transplanted: Kidney (Renal) | Dose: mean 58.0 +/- 10.0 kg | MPA AUC was lower in the patients with acute rejection compared to those without AR (40.93 vs. 53.88 μg·h/mL, p=0.038).
Study design: Non Randomized Clinical Trial | Age: Mean 40.0 +/- 12.0y | Concomitant medications:
Length of followup: NR | | Cyclosporine
| | Prednisone
| | Tacrolimus
Mourad^33^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 500mg BID + adjustment for side effects | MPA measurements at the time of acute rejection for 3 patients (5.8%) at a fixed dose of 500 mg twice daily were: MPA AUC of 37.7, 24.9, and 104.9 mg·h/L. (not much data)
Study design: Case series | Age: Range 32–68y | Concomitant medications:
Length of followup: 3 months | Median 49y | Tacrolimus
| | Corticosteroids
Satoh^30^ 2006 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day | Mean MPA AUC in patients with and without AR were 32.41 and 62.00 μg·h/L (daytime) and 24.44 and 57.88 μg·h/mL (nighttime), respectively (p≤0.02).
Study design: Case series | Age: Mean 41.2 +/- 2.1y | Concomitant medications:
Length of followup: NR | Range 21 – 66y | Tacrolimus
| | Methylprednisolone
| | Corticosteroids
Sumethkul^32^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 720 mg BID | Only very weak inferential evidence as purpose of study was to assess delivery of MPA by ECMPS and not to correlate MPA measurements with health outcomes: 3 patients (MPA AUC = 52, 125, and 139 μg·h/L) had no evidence of rejection. 1 patients (MPA AUC = 52.3 μg·h/L) showed borderline acute rejection.
Study design: Case series | Age: Mean 39 +/- 9y | Concomitant medications:
Length of followup: 3–8 months | | Cyclosporine
| | Prednisone
Takahashi^31^ 1995 | Organ transplanted: Kidney (Renal) | Dose: 1000, 2000, or 3000 mg/day | Rejection group 1: > 40 ug·h/mL MPA (1/12 patients); group 2: < 40 ug·h/mL MPA AUC (13/19 patients)
Study design: Non randomized controlled trial | Age: Inclusion requirement ≥16y | Concomitant medications:
Length of followup: 12 weeks | 1000 mg/d: Mean 37.7 +/- 6.3y | Cyclosporine
| 2000 mg/d: Mean 38.5 +/- 12.2y | steroids (no description)
| 3000 mg/d: Mean 41.0 +/- 10.3y
Weber^26^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m2 twice a day to a maximum of 2 g/day | AUC was able to discriminate between patients with and without acute rejection. AUC (HPLC) of 33.8 mg·h/L had a diagnostic sensitivity of 80% and a diagnostic specificity of 57%; AUC (EMIT) was 36.1 mg·h/L.
Study design: Case series | Age: Mean 11.8y | Concomitant medications:
Length of followup: 6 months | Range 3.2 – 16.0y | Cyclosporine A
| | Methylprednisolone
Weber^17^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m2 BSA twice a day up to 2 g/day maximum | MPA AUC was able to discriminate between patients with and without acute rejection. AUC (HPLC) of 33.8 mg·h/L had a diagnostic sensitivity of 75% and a diagnostic specificity of 64.3%.
Study design: Case series | Age: Range 2.2–17.8y | Concomitant medications:
Length of followup: 6 months | | Cyclosporine A
| | Methylprednisolone
van Gelder^12^ 1999 | Organ transplanted: Kidney (Renal) | Dose: L: 16.1 ug hr/ml I: 32.2 ug hr/ml H: 60.6 ug hr/ml | At the 3 target values for AUC (low- 16.1; intermediate- 32.2; and high- 60.6 mg.h/L, incidences of biopsy-proven acute rejection were 27.5%, 14.9%, and 11.5%, respectively (p=0.043). Note that all 3 target values were exceeded after day 21. There was a significant relation between median ln MPA AUC and biopsy-proven acute rejection (p<0.001).
Study design: RCT | Age: Range | Concomitant medications:
Length of followup: 6 months | L: 47.8 +/- 11.5y; | Cyclosporine
| I: 46.9 +/- 13.8y; | Prednisone
| H: 50.6 +/- 10.5y | Corticosteroids

Abbreviations: AR=Acute rejection, AUC=Area-under-the-concentration-time curve, BID=Twice Daily, C_0_=Predose Trough Serum or Plasma Concentration, CsA=Cyclosporin A, EMIT=Enzyme-Multiplied Immunoassay Technique, ECMPS=Enteric Coated Mycophenolate Sodium, H=High, HPLC=High-Performance Liquid Chromatographic, I=Intermediate, L=Low, LSS=Limited Sampling Strategy, MMF=Mycophenolate Mofetil, MPA=Mycophenolic Acid, NR=Not Reported, RCT=Randomized Controlled Trial, y=Years

Table 8 Studies showing some relationship between rejection and method of MPA monitoring. Limited sampling strategies - Predose (C_0_, C_min_, or C_12_)

Study | Population | Treatment | Major Findings/ Comments
Armstrong^27^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BID | MPA C_0_ cut off was 1.0 mg/L (HPLC) for acute rejection had a diagnostic sensitivity of 77.8% and specificity of 64.5%; MPA C_0_ cut off was 1.3 mg/L (EMIT)
Study design: Case series | Age: NR | Concomitant medications:
Length of followup: 70 days | | Cyclosporine
| | Methylprednisolone
| | Prednisone
Braun ^39^ 1998 | Organ transplanted: Kidney (Renal) | Dose: 30–40 mg/kg/day | Weak supporting data: All 6 patients with liver graft rejection had low MPA predose concentrations (<1 mg/L)
Study design: Prospective Cohort | Liver | Concomitant medications:
Length of followup: median 280 days (19–585) | Age: NR | Tacrolimus
Brusa^41^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 250 to 1000 mg/day BID | Very weak supporting data for therapeutic drug monitoring: The authors reported “some episodes of interstitial rejection were observed in some transplanted patients having a predose concentration below 2 μg/mL” but no data were provided
Study design: Prospective Cohort | Age: Range for 18 patients 13–58y; 5 patients 35–56y | Concomitant medications:
Length of followup: >12 months | | Cyclosporine
| | Corticosteroids
Filler^46^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BID | Weak supportive data: Other than one patient with a very low MPA predose concentration (data not provided) who experienced a steroid-sensitive rejection episode 566 days after conversion to MMF, no patient experienced rejection
Study design: Case series | Age: Mean 17.2y +/- 4.2 SD y | Concomitant medications:
Length of followup: 6.2 +/- 2.7y (2.3–11.8) | | Cyclosporine Steroids
Gajarski^44^ 2004 | Organ transplanted: Heart (Cardiac) | Dose: average 1206.8 +/- 301.9 mg/m^2^ | Endomyocardial biopsy grade ≥ 2 were associated with significantly lower MPA predose concentrations (1.05 vs. 2.3, p<0.01) compared with grades 0, 1A or 1B. Grade ≥ 2 also occurred significantly more frequently with MPA concentrations < 2.5 μg/mL (p=0.03)
Study design: Case series | Age: Mean 15.4 +/- 9.5 years | Concomitant medications:
Length of followup: NR | Range 1 month – 33 years | Cyclosporine
| | Tacrolimus
Hesse^45^ 2001 | Organ transplanted: Heart (Cardiac) | Dose: 1500 mg BID + dose reductions on clinical symptoms | Median MPA predose concentrations were significantly lower in patients with acute rejection compared to patients without acute rejection (1.36 vs. 1.76 mg/L, p=0.015)
Study design: Case series | Age: NR | Concomitant medications:
Length of followup: mean 10.1 months | | Tacrolimus
| | Prednisone
| | CsA
Krumme^47^ 1998 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Mean MPA predose (C_0_ or trough) concentrations were significantly lower in patients with rejection compared with those without rejection (1.55 vs. 2.1, p<0.005)
Study design: Case series | Age: Range 46 +/-11y | Concomitant medications:
Length of followup: 2 months | | Cyclosporine
| | Methylprednisolone
Lu^48^ 2006 | Organ transplanted: Kidney (Renal) | Dose: weight directed dosage (50 kg: 2.0 g/day) starting 2 days before transplantation | Group A: n=239 (66.9%), no adverse events or acute rejections, mean MPA C_0_ 0.8416 +/- 0.1373 mg/L group B: n=100 (28.0%), adverse events, mean MPA C0 1.5903 +/- 0.3741 mg/L and group C: n=18 (5.0%), an acute rejection, mean MPA C_0_ 0.6057 +/- 0.2338 mg/L (p<0.001, =0.021, and <0.001, between A and B, A and C, and B and C, respectively. Although ROC curve analysis showed significant correlations between MPA C_0_ and clinicial events (toxity and rejection), they did not reveal a high degree of diagnostic sensitivity (65.1 to 84.6%) or specificity (74.7 to 84.7%) according to the authors. Note that MPA C_0_ and MPA AUC were not significantly correlated (r=0.325, p=0.411) in this study. Also note Lu^120^ contains partial data (n=22); statistical significance same for both articles
Study design: Case series | Age: Mean 34.1 +/- 7.1y | Concomitant medications:
Length of followup: 6 months | Range 18 to 64y | Cyclosporine CsA, Neoral steroids
Mandla^38^ 2006 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID in combined kidney plus pancreas transplant patients 1 g TID | Acute rejection rate was 44% in patients who attained > 1 μg/mL (i.e., the suggested minimum predose concentration) and 27% in those with concentrations < 1 μg/mL (p value not given); paradoxical finding suggests that CSA may confound the relation between MPA concentrations and AR
Study design: Non randomized controlled trial | Age: Mean 54y | Concomitant medications:
Length of followup: 3 months | Range 19 –77y | Cyclosporine
| | Tacrolimus Methylprednisolone
| | Prednisone
Meiser^7,8^ 1999 | Organ transplanted: Heart (Cardiac) | Dose: 1 g BID | In Phase I, the mean MPA predose concentrations in patients who had no episodes of rejection, 1–2 rejection episodes, and 3 rejection episodes were: 3.6 vs. 2.2 vs. 1.4 μg/mL (p value not provided). In Phase 2, 3 patients (all of whom experienced only one rejection episode each) had MPA predose concentrations of 0.7, 1.3, and 0.9 μg/mL (although there were other confounding factors). The authors also suggested that mean MPA plasma concentrations > 3 μg/mL were not associated with rejection, but no details were provided
Study design: Non randomized controlled trial | Age: Inclusion requirement Phase 1 & 2: >18y | Concomitant medications:
Length of followup: Phase 1: 696 +/- 62d (606–790) Phase 2: 436 +/- 88d (175–562) | Range Phase 1: 50.6 +/- 11.4y (18–64); Phase 2: 54.1 +/- 8.9y (21–66) | Tacrolimus
| | Prednisone
| | Prednisolone
Mourad^33^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 500 mg BID + adjustment for side effects | MPA measurements at the time of acute rejection for 3 patients (5.8%) at a fixed dose of 500 mg twice daily were: MPA C_0_ of 1.86, 1.76, and 3.83 mg/L
Study design: Case series | Age: Range 32–68y | Concomitant medications:
Length of followup: 3 months | Median 49y | Tacrolimus
| | Corticosteroids
Pawinski^43^ 2006 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | C_0_ cut off of 0.8 mg/L had a diagnostic sensitivity of 59.3% and diagnostic specificity of 83.3% (better than C_max_ but worse than AUC (based on LSS of C_0_, C_0.5_, and C_2_)
Study design: Case series | Age: Mean 48y | Concomitant medications:
Length of followup: 3 months | Range 17 – 62y | Cyclosporine
| | Tacrolimus
| | Prednisone
Satoh^30^ 2006 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day | Mean MPA predose concentrations in patients with and without AR were 0.71 and 3.22 μg/mL (daytime) and 1.03 and 3.22 μg/mL (nighttime), respectively (p=0.001)
Study design: Case series | Age: Mean 41.2 +/- 2.1y | Concomitant medications:
Length of followup: NR | Range 21 – 66y | Tacrolimus Methylprednisolone
| | Corticosteroids
Tredger^40^ 2004 | Organ transplanted: Liver | Dose: adults: 500 mg BID then increased, children: 5 mg/kg BID then increased | Optimal efficacy and fewest complications in population at a predose MPA concentration around 1 mg/L. Figure 1b within this study shows the RR of rejection (95%CI) increased 4.2-fold (2.34–7.49), 2.5-fold (1.92–3.22) and 1.6-fold (1.28–2.03) at plasma MPA concentrations less than 0.5, 1.0 and 1.5 mg/L (p=0.003, 0.002 and 0.058).
Study design: Prospective Cohort | Age: Mean adults median: 50.1y, children median: 3.5 years | Concomitant medications:
Length of followup: 2 years (Feb 1 2000 – Feb 28 2002) | Range adults: 16.9 – 71.8y, children: 0.3 – 19.5y | Cyclosporine
| | Tacrolimus
Weber^26^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BID to a maximum of 2 g/day | C_0_ and C_12_ were able to discriminate between patients with and without acute rejection. C_12_ (HPLC) of 1.2 mg/L had a diagnostic sensitivity of 80% and a diagnostic specificity of 60%; C_12_ (EMIT) was 1.4 mg/L.
Study design: Case series | Age: Mean 11.8y | Concomitant medications:
Length of followup: 6 months | Range 3.2 – 16.0y | Cyclosporine
| | Methylprednisolone
van Gelder^12^ 1999 | Organ transplanted: Kidney (Renal) | Dose: L: 16.1 μg hr/ml | There was a significant relation between median ln C_0_ and biopsy-proven acute rejection (p=0.01)
Study design: RCT | Age: Range L: 47.8 +/- 11.5y; I: 46.9 +/- 13.8y; H: 50.6 +/- 10.5y | I: 32.2 μg hr/ml
Length of followup: 6 months | | H: 60.6 ug hr/ml
| | Concomitant medications:
| | Cyclosporine
| | Prednisone
| | Corticosteroids
Yamani^42^ 2000 | Organ transplanted: Heart (Cardiac) | Dose: 2 g/day | In the first year post-transplant, the incidence of rejection was significantly lower in the patient samples with MPA predose concentrations > 2 mg/L compared with those < 2 mg/L (8.8 vs. 14.9% at < 6 months, p=0.05 and 4.2 vs. 11.3% at 6–12 months, p=0.05). When CSA or TAC concentrations were “therapeutic”, the incidence of rejection was significantly lower at MPA predose concentrations of ≥ 2 mg/L compared with those < 2 mg/L (3.6 vs. 14.4%, p=0.005)
Study design: Retrospective Cohort | Age: Mean 36 +/- 14y | Concomitant medications:
Length of followup: 179 +/- 52 days | | Cyclosporine
| | Tacrolimus
| | Prednisone

Abbreviations: AR=Acute rejection, AUC=Area-under-the-concentration-time curve, BID=Twice Daily, C_0_=Predose Trough Serum or Plasma Concentration, CsA=Cyclosporin A, EMIT=Enzyme-Multiplied Immunoassay Technique, H=High, HPLC=High-Performance Liquid Chromatographic, I=Intermediate, L=Low, LSS=Limited Sampling Strategy, MMF=Mycophenolate Mofetil, MPA=Mycophenolic Acid, NR=Not Reported, RCT=Randomized Controlled Trial, ROC=Receiver Operating Characteristic, RR=Relative Risk, TAC=Tacrolimus; TID=Three times per day; SD= Standard Deviation, y=Years

Table 9 Studies showing some relationship between rejection and method of MPA monitoring. Limited sampling strategies - 2h Post (C_2_)

Study | Population | Treatment | Major Findings/ Comments
Kiberd^57^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day fixed | Day 3 MPA C_2_ significantly (p=0.025) predicted later rejection.
Study design: Case series | Age: Mean 48 +/- 13y | Concomitant medications:
Length of followup: 3 months | | Prednisone
| | Neoral

Abbreviations: MPA=Mycophenolic Acid, y=Years

Table 10 Studies showing some relationship between rejection and method of MPA. Limited sampling strategies - Other

Study | Population | Treatment | Major Findings/ Comments
DeNofrio^19^ 2000 | Organ transplanted: Heart (Cardiac) | Dose: 1g BID | Lower MPA AUC (as predicted by LSS of C_0_, C_20min_, C_40min_, C_75min_, and C_120min_) was associated with cardiac allograft rejection. Specifically, MPA AUC values were significantly lower in patients with Grade 2/3 than in patients with Grade 1 rejection (26.1 vs. 51.7 mg·h/L, p< 0.05)
Study design: Case series | Age: Mean 53 +/- 10y | Concomitant medications:
Length of followup: 310 +/- 278 days | | Cyclosporine
Kiberd^57^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day fixed | Day 3 MPA AUC (based on LSS of C_0_, C_1_, C_2_, and C_4_) significantly predicted later rejection (p=0.007). The best cutoff point was an AUC concentration of 22 mg*h/L (sensitivity 82%, specificity 64%, negative predictive value 89% and positive predictive value 30%)
Study design: Case series | Age:Mean 48 +/- 13y | Concomitant medications:
Length of followup: 3 months | | Prednisone
| | Neoral
Kuriata-Kordek^54^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 2.0 g/dayay | C_40min_ values were significantly lower in the patients with acute rejection compared with those without acute rejection (6.47 vs. 18.5 mg/L, p<0.05)
Study design: Case control | Age: Inclusion requirement group I: 38.12 +/- 9.5y, group II: 38.52 +/- 9.21y | Concomitant medications:
Length of followup: 12 months | | Cyclosporine
| | Prednisone
Le Meur^10^ 2007 | Organ transplanted: Kidney | Fixed dose group: 1g BID; Concentration-controlled group: Days 1–7, 1g BID, then dose to target AUC of 40 mg*h/L | Incidence of treatment failure, the primary study endpoint, was significantly lower in the concentration-controlled group (that used LSS of C_20min_, C_1_, and C_3_ developed by Bayesian methods, to target an AUC of 40 mg*h/L) compared with the fixed dose group (29.2% vs. 47.7%, p=0.03); percentage of acute rejection (12.3% vs. 30.7%, p=0.01) and biopsy-proven acute rejection (7.7% vs. 24.6%) were also lower in the concentration-controlled group.
Study design: RCT | Age: | Concomitant medications:
Length of followup: 12 months | Fixed dose group 49 +/- 13y | Cyclosporine
| Concentration-controlled group: 50 +/- 14y | Methylprednisolone
| | Basiliximab
| | Trimethoprim-sulfamethoxazole
Okamoto^49^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 25 mg/kg initially, then adjusted afterwards | MPA AUC_0–9_ was significantly lower in patients with AR compared with those without (28.2 vs. 34.2 μg·h/mL, p=0.04085)
Study design: Non randomized controlled trial | Age: Mean 38 +/- 14y | Concomitant medications:
Length of followup: NR | | Cyclosporine n=35
| | Tacrolimus n=32
Pawinski^64^ 2006 | Organ transplanted: Kidney (Renal) | Dose: 0.5 – 2 g/day | AUC (based on LSS of C_0_, C_0.5_, and C_2_) cut off for acute rejection of 27.5 mg·h/L had a diagnostic sensitivity of 81.2% and a diagnostic specificity of 93.4% (i.e., best predictor of acute rejection)
Study design: Case series | Age: Range 17 – 62y | Concomitant medications:
Length of followup: 3 months | | Cyclosporine
| | Tacrolimus
| | Prednisone
Pawinski^43^ 2006 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | AUC (based on LSS of C_0_, C_0.5_, and C_2_) cut off of 24.1 mg·h/L had a diagnostic sensitivity of 77.8% and diagnostic specificity of 91.7% (best compared with predose and C_max_)
Study design: Case series | Age: Mean 48y | Concomitant medications:
Length of followup: 3 months | Range 17 – 62y | Cyclosporine
| | Tacrolimus
| | Prednisone
Pillans^59^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day | MPA AUC (as predicted by a LSS of C_0_, C_1_, C_3_, and C_6_) was significantly lower in patients experiencing biopsy-proven rejection compared to those without rejection (27.6 vs. 35.1 mg·h/L, p=0.02). Four of 14 patients (29%) with an MPA AUC > 30 mg·h/L had a rejection episode but 8 of 13 patients (62%) with an MPA AUC <30 mg·h/L experienced a rejection
Study design: Case series | Age: Range 21–65y | Concomitant medications:
Length of followup: 1 month | | Cyclosporine
| | Prednisone
Weber^63^ 2006 | Organ transplanted: Kidney (Renal) | Dose: German study: 600 mg/m^2^ BSA up to 2 g/day suspension trial: 600 mg/m^2^ body surface area BID (up to 1000 mg BID), corresponding to 1 g MMF BID in adult renal transplant recipients | AUC (based on LSS of C_0_, C_0.5_, and C_2_) was able to discriminate patients with acute rejection from those with no rejection; AUC cut off of 36.8 mg.h/L had prognostic sensitivity of 66.7% and prognostic specificity of 61.9%
Study design: Case series | Age: Range German study: 3.17–16.0y, Suspension trial: 1.0–16.0y | Concomitant medications:
Length of followup: 6 months post-transplant suspension trial: 36 months | | Cyclosporine CsA microemulsion: German study and suspension trial
| | Methylprednisolone German study
| | Prednisone suspension trial
| | Corticosteroids
Weber^26^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BID to a maximum of 2 g/day | AUC (based on LSS of C_0_, C_75min_, and C_4_) was able to discriminate between patients with and without acute rejection
Study design: Case series | Age: Mean 11.8y | Concomitant medications:
Length of followup: 6 months | Range 3.2–16.0y | Cyclosporine A
| | Methylprednisolone
Weber^17^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BSA BID up to 2 g/day max | AUC (based on LSS of C_0_, C_75min_, and C_4_) was able to discriminate between patients with and without acute rejection
Study design: Case series | Age: Range 2.2–17.8y | Concomitant medications:
Length of followup: 6 months | | Cyclosporine A
| | Methylprednisolone

Abbreviations: AR=Acute rejection, AUC=Area-under-the-concentration-time curve, BID=Twice Daily, BSA=Body Surface Area, C_0_=Predose Trough Serum or Plasma Concentration, C_max_=Maximum Serum or Plasma Concentration, CsA=Cyclosporin A, LSS=Limited Sampling Strategy, MMF=Mycophenolate Mofetil, MPA=Mycophenolic Acid, NR=Not Reported, RCT=Randomized Controlled Trial, y=Years

Table 11 Studies showing no relationship between rejection and method of MPA monitoring

Study | Population | Treatment | Major Findings/ Comments
Kuypers^36^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 0.5 g BID or 1 g BID | Same study as ^52^ (Prospective Cohort)
Study design: Case series | Age: Median 51.5y | Concomitant medications: | MPA AUC (56.5 vs. 46 mg.h/L, p=0.84) was not significantly lower between patients with later experienced acute rejection and those who did not. Incidence of acute rejection was numerically, but not significantly higher for patients who did not attain both target tacrolimus AUC of 150 ng.h/mL and MPA AUC of 45 mg.h/L by Day 7 compared with patients who did (26.3% vs. 7.7%, p=0.07). Note that a full AUC_0–12_ was obtained on Day 7, a 2-h AUC at week 6, and a 4-h AUC at months 3,6, and 12 (the 2- and 4-h AUCs were used to predict AUC_0–12_)
Length of followup: 12 months | | Tacrolimus
| | Methylprednisolone
| | Daclizumab
Mourad^37^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | MPA AUC data were similar with 15.5, 72.7, and 42.1 ug *h/mL associated with rejection, adverse events, and uneventful outcomes, respectively (p value not provided)
Study design: Case series | Age: Mean 46y | Concomitant medications:
Length of followup: 12 weeks | Range 33–57y | Cyclosporine
| | Prednisolone
Reggiani^34^ 2001 | Organ transplanted: Liver | Dose: 750 mg BID 1st month, 500 mg BID > 1 month | No difference in MPA AUC was observed in patients with acute rejection compared to those without (p value not provided)
Study design: RCT | Age: Mean A: 49.7 +/- 4.6y, | Concomitant medications:
Length of followup: mean 31 +/- 7 months | group B: 50.4 +/- 8.9y | Tacrolimusgroup A and B
| | Methylprednisolone group B
| | Prednisone group B
Satoh^35^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 1.0 – 2 g/day | There was no significant difference in MPA AUC in patients with AR compared to those without AR (32.2 vs. 59.5 μg·h/L, p=0.081)
Study design: Prospective Cohort | Age: Mean AZA: 37.9 +/- 11.5y | Concomitant medications:
Length of followup: 28 days | MMF: 44.3 +/- 11.6y | Tacrolimus
| | Methylprednisolone
| | Prednisone

Abbreviations: AR=Acute rejection, AUC=Area-under-the-concentration-time curve, AZA=Azathioprine, BID=Twice Daily, MMF=Mycophenolate Mofetil, MPA=Mycophenolic Acid, RCT=Randomized Controlled Trial, y=Years

Table 12 Studies showing no relationship between rejection and method of MPA monitoring. Limited sampling strategies - Predose (C_0_, C_min_, or C_12_)

Study | Population | Treatment | Major Findings/ Comments
Barbari^53^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID range 1 – 2.5 g/day | There was a poor association between clinical events (primarily rejection, but also lymphocyte counts [an indicator of immune responsiveness]) and predose MPA concentrations. (r^2^=0.0803 and 0.0577, respectively; Fig. 2, 3 and 4, p. 357 in study)
Study design: Case control | Age: Mean 39y | Concomitant medications:
Length of followup: NR | Range 20 – 67y | Cyclosporine
| | Prednisone
Behrend ^25^ 1997 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day or 3 g/day; dose per body weight was 22 to 54 mg/Kg; mean 83 mg/kg + - 8.4 body weight | Very very weak supportive data: The authors state that “there is no clearcut relationship between plasma concentrations and rejection, adverse events, and infections” but provide no data. Also, they state that interindividual variability in MPA predose (or C_0_ or predose) concentrations is “by far greater than the correlation to ...dose...” but do not provide specific data
Study design: RCT | Age: NR | Concomitant medications:
Length of followup: at least 1 year | | Cyclosporine
| | Corticosteroids
Bilbao^62^ 2006 | Organ transplanted: Liver | Dose: Initial dose of 500 mg/12h; reaching dose of 1 g each 12h for 2 weeks | The authors stated that “We have not found any correlation between MMF predose concentrations and the occurrence of rejections” but provided no data to substantiate this statement
Study design: Case series | Age: Mean 59 +/- 6y | Concomitant medications:
Length of followup: mean 39 + - 20 months; range 3 to 72 months | | Cyclosporine
| | Tacrolimus
Cantin^58^ 2002 | Organ transplanted: Heart (Cardiac) | Dose: Tac group: 1810 mg/day +/- 817, CsA group: 2447 +/- 896 | No significant difference was observed in the incidence of overall rejection or high-grade rejection between patients with MPA predose concentrations < 2 mg/L and those with MPA concentrations ≥ 2 mg/L. However, both episodes of high grade (3A) rejection occurred in patients with MPA concentrations < 2 mg/L. The authors conclude that “There does not appear to be a benefit in continued monitoring of plasma mycophenolic acid concentrations beyond the first year of heart transplantation.”
Study design: Case series | Age: Mean 54.4 +/- 14y | Concomitant medications:
Length of followup: 1 year | Range 22–72y | Cyclosporine
| | Tacrolimus
| | Corticosteroids
DeNofrio^19^ 2000 | Organ transplanted: Heart (Cardiac) | Dose: 1 g BID | MPA C_0_ in Grade 2/3 vs. Grade 0 rejection (0.65 vs. 1.20 mg/L, p=0.15)* *note that authors state these as positive findings, but they are actually not statistically significant
Study design: Case series | Age: Mean 53 +/- 10y | Concomitant medications:
Length of followup: 310 +/- 278 days | | Cyclosporine
Dipchand^55^ 2001 | Organ transplanted: Heart (Cardiac) | Dose: various: 15–159 mg/kg | A therapeutic predose MPA concentration was considered to be > 3 μg/mL. In the first 8 weeks post-transplant there were 7 rejection episodes in 6 patients with therapeutic concentrations and 4 patients with no rejection. There were 5 rejection episodes in 4 patients who had no therapeutic concentrations and 6 patients with no rejection. While the authors state “serum predose MPA concentrations may relate to efficacy”, this is not substantiated by these data
Study design: Retrospective Cohort | Age: Range 29 days–23.5y | Concomitant medications:
Length of followup: 8 weeks | Median 6.3y | Cyclosporine (A or neoral)
| | Tacrolimus
| | Corticosteroids azathiaprine
| | ATG
| | OKT3 (Monoclonal Antibody)
| | ATS
Hale^11^ 1998 | Organ transplanted: Kidney (Renal) | Dose: L: 0.45 g BID then adjusted | In bivariate logistic regression analysis, biopsy-proven rejection vs. MPA C_0_ was not significant (p>0.05)
Study design: RCT | Age: Inclusion requirement > 18y | I: 0.95 g BID then adjusted
Length of followup: 20 weeks | Range: | H: 1.7 g BID then adjusted
| L: 47.8 +/- 11.5 y, | Concomitant medications:
| I: 46.9 +/- 13.8y, | Cyclosporine
| H: 50.6 +/- 10.5y | Corticosteroids
Hazzan^28^ 2005 | Organ transplanted: Kidney (Renal) | Dose: CsA group MMF dose = 1.93 +/- 0.2 g/day then withdrawn to 0, MMF group MMF dose = 1.99 +/- 0.1 g/day | MPA predose concentration was not associated with risk for AR in multivariate analysis, p>0.05
Study design: RCT | Age: Mean CsA group 42.5 +/- 12.1y MMF group 45.1 +/- 11.2y | Concomitant medications:
Length of followup: 1 year | | Cyclosporine
| | Prednisone
Hesse^45^ 2001 | Organ transplanted: Heart (Cardiac) | Dose: 1500 mg BID + dose reductions on clinical symptoms | There was no significant correlation between predose MPA concentrations and graft histology (endomyocardial biopsy scores). The authors state that they “do not find a significant correlation between MPA predose concentrations and the incidence of AR”
Study design: Case series | Age: NR | Concomitant medications:
Length of followup: Mean 10.1 months | | Tacrolimus
| | Prednisone
| | CsA
Hubner^56^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 1.0 g BID | Did not observe relation between predose concentration and rejection, but no rejection episodes occurred during MMF administration despite varying predose concentrations
Study design: Case series | Age: Mean 45y | Concomitant medications:
Length of followup: NR | | Cyclosporine A
| | Methylprednisolone
Kiberd^57^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day fixed | Day 3 MPA C_0_ did not significantly predicted later rejection (p=0.08)
Study design: Case series | Age: Mean 48 +/- 13y | Concomitant medications:
Length of followup: 3 months | | Prednisone
| | Neoral
Kuriata-Kordek^54^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 2.0 g/day | No significant difference was observed between patients with or without acute rejection within 3 months post-transplant in C_0_. No significant difference was observed between patients with or without acute rejection during the 1-year followup.
Study design: Case control | Age: Inclusion requirement group I: 38.12 +/- 9.5y, group II: 38.52 +/- 9.21y | Concomitant medications:
Length of followup: 12 months | | Cyclosporine
| | Prednisone
Kuypers^36^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 0.5 g BID or 1 g BID | Same study as ^52^ (Prospective Cohort)
Study design: Case series | Age: Median 51.5y | Concomitant medications: | Day 7 MPA C_0_ (1.5 vs. 2.1 mg/L, p=0.90) was not significantly lower between patients with later experienced acute rejection and those who did not.
Length of followup: 12 months | | Tacrolimus
| | Methylprednisolone
| | Daclizumab (31 patients)
Kuypers^52^ 2003 | Organ transplanted: Kidney (Renal) | Dose: 1 g/day or 2 g/day | Same study as ^36^[Case series]
Study design: Prospective Cohort | Age: Mean 51.5y | Concomitant medications: | Biopsy-proven acute rejection was not related to MPA C_0_ (2.49 vs. 2.15 mg/L, rejection vs. no rejection, respectively; p=0.9). The time course of MPA exposure (i.e., AUC) was related more to MMF dose than to MPA predose concentrations. That is, MPA AUC increased by ~40% in the first 6 weeks post-transplant in the 2 g MMF group, but by only 17% in the 1g MMF group. At 3 months post-transplant, the 2-g group's MPA AUC declined minimally whereas the 1 g group's AUC decreased to its nadir. In both groups, MPA AUC returned to baseline values. Thus, the authors suggest that using MPA predose concentrations in routine therapeutic drug monitoring may be misleading regarding efficacy or toxicity
Length of followup: 12 months | | Tacrolimus
| | Methylprednisolone
| | Daclizumab (31 patients)
Kuypers^15^ 2003 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Predose MPA concentrations (C_0_) were not significantly different in patients with or without acute rejection or drug-related adverse events. The authors recommend that “A large randomized comparative trial examining the usefulness of frequent, more extensive pharmacokinetic measurements like area under the curve for MPA and its metabolites, is mandatory to answer the question.”
Study design: Case series | Age: Mean 49.4 +/- 13.1y | Concomitant medications:
Length of followup: 12 months | | Methylprednisolone
| | Tacrolimus
| | Daclizumab
Kreis^50^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | There was no significant difference in mean MPA predose concentrations between patients with and without acute rejection in either the concomitant sirolimus (3.06 vs. 3.48, p=0.50) or cyclosporine (1.71 vs. 2.20, p=0.39) group. Although the concentrations were higher, the small sample size limited statistical inference
Study design: RCT | Age: Range | Concomitant medications:
Length of followup: 6 months | SIR: 43.5 +/- 10.9y (22–62y); | Cyclosporine
| CsA: 42.9 +/- 11.4 y (18–60y) | Corticosteroids
| | Sirolimus
Mourad^37^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Mean MPA predose concentrations were different for rejection vs. those experiencing MMF toxicity (1.3 vs. 3.1 mg/L, p<0.05); however, they were not significantly different for those experiencing rejection compared to those experiencing neither adverse events or rejection (1.3 vs. 2.2 mg/L, p>0.05)
Study design: Case series | Age: Mean 46y | Concomitant medications:
Length of followup: 12 weeks | Range 33–57y | Cyclosporine
| | Prednisolone
Okamoto^49^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 25 mg/kg initially, then adjusted | MPA predose concentration was not significantly different in patients with and without AR
Study design: Non randomized controlled trial | Age: Mean 38 +/- 14y | Concomitant medications:
Length of followup: NR | | Cyclosporine n=35
| | Tacrolimus n=32
Orlando^61^ 2006 | Organ transplanted: Liver | Dose: 250 mg per os BID increased weekly by 500 mg to dose of 1500 mg/day | Mean MPA predose (C_0_ or trough) concentrations were not signficantly different between rejectors and non-rejectors (data provided in graphical form). Rejection episodes all occurred at “therapeutic” or “supratherapeutic” MPA predose concentrations (range of 1.5 to 7.2 mg/L)
Study design: Case series | Age: Mean 60.1y | Concomitant medications:
Length of followup: mean 31.5 + - 6.1 months | Range 35–67y | Cyclosporine
| | Tacrolimus
Pillans^59^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day | No significant difference was observed in MPA C_0_ in patients with and without rejection
Study design: Case series | Age: Range 21–65y | Concomitant medications:
Length of followup: 1 month | | Cyclosporine
| | Prednisone
Smak Gregoor^60^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID, 750 mg BID, 500 mg BID | No significant difference was observed between median MPA predose (C_0_ or troughs) concentrations in 3 patients experiencing an acute rejection compared with the 24 patients who did not (2.3 vs. 3.8 mg/L), although patients with MPA predose concentrations > 3.5 mg/L did not experience rejection. Given the significant relation between MMF dose and MPA predose concentrations at 4 and 8 months (p=0.0002) and 12 months (p=0.01) and the lack of significant correlation with MPA predose concentrations and rejection, these results do not support routine monitoring of MPA predose concentrations
Study design: Case series | Age: NR | Concomitant medications:
Length of followup: 1 year | | Prednisone
Tsaroucha^24^ 2000 | Organ transplanted: Kidney (Renal) | Dose: liver: 0.0258 g/kg/day | Mean MPA predose was not significantly different between the patients who experienced rejection and those who did not (0.95 vs. 1.06 mg/L, p=0.74)
Study design: Prospective Cohort | Liver | small bowel: 0.0822 g/kg/day
Length of followup: liver-165d; small bowel-58d; kidney-373d; all post transplant | Small bowel | kidney: 0.0194 g/kg/day
| Age: Mean | Concomitant medications:
| liver: 41.4 +/- 4.6y; | Tacrolimus
| small bowel: 18.7 +/- 3.9y; | Steroids
| kidney: 44.3 +/- 2.7y
Wang^51^ 1998 | Organ transplanted: Kidney (Renal) | Dose: 1. 1.0 g BID | Very very weak supportive data: No significant differences were observed in mean C_max_, C_min_, or AUC_0–12_ for patients in the MMF 1 g BID vs. 0.75 g BID groups. One patient in the MMF 1 g BID group and no patients in the 0.75 g BID group had an acute rejection epsiode. The authors also reported that “There were no obvious differences on MMF side effects between group 1 and group 2” but no data were given
Study design: RCT | Age: Range 35–59y | 2. 0.75 g BID
Length of followup: 3 months | | Concomitant medications:
| | Cyclosporine
| | Corticosteroids
| | Prednisone
| | Methylprednisolone
Weber^17^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BSA BID up to 2 g/day max | MPA C_0_ did not perform as well (p=0.07, respectively) in discriminating between rejectors and non-rejectors
Study design: Case series | Age: Range 2.2 – 17.8y | Concomitant medications:
Length of followup: 6 months | | Cyclosporine A
| | Methylprednisolone
Yamani^42^ 2000 | Organ transplanted: Heart (Cardiac) | Dose: 2 g/day | There was no significant difference in incidence of rejection at >12 months in the patient samples with MPA predose concentrations > 2 mg/L compared with those < 2 mg/L (11.3 vs. 11.7%, p=0.92). There was also no significant difference in mean MMF predose concentrations between samples with and without rejection at any time post-transplant. When C_S_A or TAC concentrations were “therapeutic”, the incidence of rejection was significantly lower at MPA predose concentrations of > 2 mg/L compared with those < 2 mg/L (3.6 vs. 14.4%, p=0.005), but when C_S_A or TAC concentrations were “subtherapeutic”, there was no significant difference in incidence of rejection at MPA predose concentrations of > 2 mg/L vs. < 2 mg/L (15.4 vs. 13.9%, p>0.05)
Study design: Retrospective Cohort | Age: Mean 36 +/- 14y | Concomitant medications:
Length of followup: 179 +/- 52 days | | Cyclosporine
| | Tacrolimus
| | Prednisone

Abbreviations: AR=Acute rejection, ATG=Anti-Thymocyte Globulin, ATS=Anti-Tserum, AUC=Area-under-the-concentration-time curve, BID=Twice Daily, BSA=Body Surface Area, C_0_=Predose Trough Serum or Plasma Concentration, C_max_=Maximum Serum or Plasma Concentration, C_min_=Minimum Serum or Plasma Concentration, CsA=Cyclosporin A, H=High, I=Intermediate, MMF=Mycophenolate Mofetil, MPA=Mycophenolic Acid, NR=Not Reported, RCT=Randomized Controlled Trial, SIR=Sirolimus, TAC=Tacrolimus, y=Years

Table 13 Studies showing no relationship between rejection and method of MPA monitoring. Limited sampling strategies - 2h post (C_2_)

Study | Population | Treatment | Major Findings/ Comments
Kuriata - Kordek^54^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 2.0 g/day | No significant difference was observed between patients with or without acute rejection within 3 months post-transplant in C_2_. No significant difference was observed between patients with or without acute rejection during the 1-year followup in C_2_
Study design: Case control | Age: Inclusion requirement | Concomitant medications:
Length of followup: 12 months | group I: 38.12 +/- 9.5y, | Cyclosporine
| group II: 38.52 +/- 9.21y | Prednisone

Table 14 Studies showing no relationship between rejection and method of MPA monitoring. Limited sampling strategies - Other

Study | Population | Treatment | Major Findings/ Comments
Atcheson^13^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID =10 | MPA AUC (as predicted by LSS of C_0_, C_1_, C_3_, C_6_) was not significantly different between patients with and without biopsy-proven rejection (18.2 vs. 22.7 mg.h/L, p=0.25)
Study design: Prospective Cohort | Age: Mean 44.3 +/- 13.1y | Concomitant medications:
Length of followup: 1 month | | Cyclosporine n=32
| | Tacrolimus n=10
| | Simulect
| | Diltiazem
| | Prednisolone
Hale^11^ 1998 | Organ transplanted: Kidney (Renal) | Dose: | Bivariate logistic regression between biopsy-proven rejection vs. MPA C_max_ was not significant
Study design: RCT | Age: Inclusion requirement > 18 y | L: 0.45 g BID then adjusted
Length of followup: 20 weeks | Range: | I: 0.95 g BID then adjusted
| L: 47.8 +/- 11.5 y, | H: 1.7 g BID then adjusted
| I: 46.9 +/- 13.8y, | Concomitant medications:
| H: 50.6 +/- 10.5y | Cyclosporine
| | Corticosteroids
Kuriata - Kordek^54^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 2.0 g/day | No significant difference was observed between patients with or without acute rejection within 3 months post-transplant in C_60min_ or C_max_. No significant difference was observed between patients with or without acute rejection during the 1 year followup in C_60min_ or C_max_
Study design: Case control | Age: Inclusion requirement | Concomitant medications:
Length of followup: 12 months | group I: 38.12 +/- 9.5y, | Cyclosporine
| group II: 38.52 +/- 9.21y | Prednisone
Kuypers^36^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 0.5 g BID or 1 g BID | Same study as ^52^ (Prospective Cohort)
Study design: Case series | Age: Mean 51.5y | Concomitant medications: | MPA C_max_ (10.9 vs. 13 mg/L, p=0.46) was not significantly lower between patients with later experienced acute rejection and those who did not
Length of followup: 12 months | | Tacrolimus
| | Methylprednisolone
| | Daclizumab
Kuypers^52^ 2003 | Organ transplanted: Kidney (Renal) | Dose: 1 g/day or 2 g/day | Same study as ^36^ (Case Series)
Study design: Prospective Cohort | Age: Mean 51.5y | Concomitant medications: | MPA C_max_ (10.95 vs. 13.0 mg/L; p=0.4) was not significantly different between patients with and without biopsy-proven rejection
Length of followup: 12 months | | Methylprednisolone
| | Tacrolimus
| | Daclizumab (31 patients)
Mudge^65^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | MPA AUC (as predicted by LSS of C_0_, C_1_, C_3_, and C_6_) was not significantly lower in individuals with rejection and those without (30.7 vs. 34 mg.h/L, p=0.40)
Study design: RCT | Age: Mean 45.2 +/- 13.2y | Concomitant medications:
Length of followup: July 2002 – Feb 2003 | | Cyclosporine
| | Tacrolimus
| | Prednisone
Wang^51^ 1998 | Organ transplanted: Kidney (Renal) | Dose: 1. 1.0 g BID | Very very weak supportive data: No significant differences were observed in mean C_max_, C_min_, or AUC_0–12_ for patients in the MMF 1 g BID vs. 0.75 g BID groups. One patient in the MMF
Study design: RCT | Age: Range 35–59y | 2. 0.75 g BID | 1 g BID group and no patients in the 0.75 g BID group had an acute rejection epsiode. The authors also reported that “There were no obvious differences on MMF side effects between group 1 and group 2” but no data were given
Length of followup: 3 months | | Concomitant medications:
| | Cyclosporine
| | Corticosteroids
| | Prednisone
| | Methylprednisolone
Weber^26^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m BID to a maximum of 2 g/day | C_max_ and AUC_0–2_ (i.e., C_0_, C_75min_, and C_4_) did not perform as well (p=0.24 and p=0.06, respectively) in discriminating between rejectors and non-rejectors
Study design: Case series | Age: Mean 11.8y | Concomitant medications:
Length of followup: 6 months | Range 3.2–16.0y | Cyclosporine A
| | Methylprednisolone
Weber^17^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BSA BID up to 2 g/day max | C_max_ did not perform as well (p=0.10) in discriminating between rejectors and non-rejectors
Study design: Case series | Age: Range 2.2–17.8y | Concomitant medications:
Length of followup: 6 months | | Cyclosporine
| | Methylprednisolone

Abbreviations: AUC=Area-under-the-concentration-time curve, Adj=adjust, BID=Twice Daily, BSA=Body Surface Area, C_0_=Predose Trough Serum or Plasma Concentration, C_max_=Maximum Serum or Plasma Concentration, H=High, I=Intermediate, L=Low, LSS=Limited Sampling Strategy, MMF=Mycophenolate Mofetil, MPA=Mycophenolic Acid, RCT=Randomized Controlled Trial, y=Years

In the first published RCT that involved direct, head-to-head comparisons of monitoring versus no monitoring, Le Meur et al.^10^ found that the incidence of treatment failure (composite of death, graft loss, acute rejection, and MMF discontinuation) was significantly lower in the concentration-controlled group (that used LSS of C_20min_,C_1_, and C_3_ developed by Bayesian methods, to target an AUC of 40 mg h/L) compared with the fixed dose group (29.2 percent vs. 47.7 percent, p=0.03). The percentage of acute rejection (12.3 percent vs. 30.7 percent, p=0.01) and biopsy-proven acute rejection (7.7 percent vs. 24.6 percent, p=0.01) were also lower in the concentration-controlled group. Cox proportional hazards regression analyses also found that the group factor (concentration-controlled vs. fixed dose) was the most powerful indicator of acute rejection (hazard rate ratio [HRR]=1.67, p=0.017); after other nonsignificant variables were deleted, the group factor was the only significant predictor of acute rejection (HRR=1.65; 95 percent CI=1.09, 2.54; p=0.02).^10^

An RCT^11,12^ in which kidney transplant recipients were assigned to one of three pre-defined MPA AUC_0–12_ showed incidences of biopsy proven acute rejection to be 27.5 percent, 14.9 percent, and 11.5 percent respectively in each group (p=0.043). Although all three target values were exceeded after day 21, there was a significant association between the median natural logarithm of MPA AUC_0–12_ and biopsy proven acute rejection (p<0.001). Based on logistic regression analysis, MPA AUC_0–12_ values of 15 mg·h/L, 25 mg·h/L, and 40 mg·h/L are expected to yield 50 percent, 75 percent, and 90 percent of maximal achievable efficacy (with a 4 percent change in efficacy for every 1 mg·h/L change in AUC at the midpoint of the logistic curve). Univariate logistic regression p-values between biopsy proven rejection vs. MPA AUC_0–12_, MPA C_max_, MPA C_0_, and MMF dose were: < 0.0001, 0.0008, 0.0049, and 0.0918, respectively. The authors write that statistical significance is lost when only the first three predose concentrations are used in the logistic regression analysis. Consequently, they caution against basing dosage adjustments on a limited number of predose concentrations.^12^

Another study (two reports)^7,8^ reported rejection outcomes for patients on fixed dose MMF (phase I) versus patients whose MMF dose was adjusted to meet target MPA predose concentrations of 2.5 to 4.5 mg/L (phase II). In the phase I group, the mean MPA predose concentrations were 3.6 mg/L with no episodes of rejection, 2.2 mg/L with one or two rejection episodes, and 1.5 mg/L with three rejection episodes (p-value not provided). In the phase II group, three patients (all of whom experienced only one rejection episode each) had MPA predose concentrations of 0.7 mg/L, 1.3 mg/L, or 0.9 mg/L. The authors also suggested that mean MPA plasma predose concentrations greater than 3.0 mg/L were not associated with rejection, although no details were provided in the reports.

In an RCT of kidney transplant recipients, Hazzan et al.^28^ found that an MPA AUC_0–12_ cut off of 50 mg·h/L was associated with risk for acute rejection in a multivariable Cox regression analysis (adjusted hazard ratio: 0.79; 95 percent CI: 0.64 to 0.98). The authors suggested that this cut off “needs to be confirmed by further investigations”. In the same study, an MPA predose concentration cut off of 0.5 mg/L was not associated with risk for acute rejection in the multivariable model, but it was associated in a simple Cox model (unadjusted hazard ratio: 0.53; 95 percent CI: 0.30 to 0.94).

In nine case series, ROC curves were generated to determine whether a particular PK parameter could differentiate patients with acute rejection from patients without acute rejection. Weber et al.^26^ found that C_0_, C_12_, AUC_0–12_, and AUC (based on C_0_, C_75min_, C_4_) were able to differentiate between pediatric kidney transplant recipients with and without acute rejection. An AUC_0–12_ of 33.8 mg.h/L (measured using HPLC assay) had a diagnostic sensitivity of 80 percent and a diagnostic specificity of 57 percent; AUC_0–12_ (measured using EMIT assay) was 36.1 mg.h/L. A C_12_ (HPLC) of 1.2 mg/L had a diagnostic sensitivity of 80 percent and a diagnostic specificity of 60 percent; C_12_ (EMIT) was 1.4 mg/L. In contrast, C_max_ and AUC (based on C_0_, C_0.5_, C_2_) did not perform as well (p=0.24 and p=0.06 respectively) in differentiating between rejectors and non-rejectors.^26^ Weber et al.,^17^ in a second case series of pediatric kidney transplant recipients, found MPA C_12_, AUC_0–12_, AUC (based on C_0_, C_75min_, C_4_), and AUC (based on C_0_, C_0.5_, C_2_) were able to differentiate between patients with and without acute rejection. An AUC_0–12_ (HPLC) of 33.8 mg·h/L had a diagnostic sensitivity of 75 percent and a diagnostic specificity of 64.3 percent. A C_12_ (HPLC) of 1.2 mg/L had a diagnostic sensitivity of 83.3 percent and a diagnostic specificity of 64.3 percent. Conversely, C_0_ and C_max_ did not perform as well (p=0.07 and p=0.10 respectively) in differentiating between rejectors and non rejectors. In their third case series of pediatric kidney transplant recipients, Weber et al.^63^ again found that AUC (based on C_0_, C_0.5_, C_2_) was able to differentiate between patients with and without rejection. An AUC cut off of 36.8 mg·h/L had a prognostic sensitivity of 66.7 percent and a prognostic specificity of 61.9 percent.^63^

Results from the other six case series are as follows: Armstrong et al.^27^ showed that an MPA AUC_0–12_ cut off of 29.5 mg·h/L (HPLC) for acute rejection in pediatric kidney transplant recipients had a diagnostic sensitivity of 66.7 percent and a diagnostic specificity of 79.4 percent; MPA AUC_0–12_ cut off was 36.1 mg·h/L (EMIT). An MPA C_0_ cut off of 1.0 mg/L (HPLC) for acute rejection had a diagnostic sensitivity of 77.8 percent and specificity of 64.5 percent; MPA C_0_ (EMIT) was 1.3 mg/L.^27^ The ROC curve analysis performed by Lu et al.^48^ in kidney transplant recipients showed significant correlations between MPA C_0_ and clinicial events (toxity and rejection), and revealed a diagnostic sensitivity (65.1 to 84.6 percent) and specificity (74.7 to 84.7 percent). Pawinski et al.^64^ found that an AUC (based on C_0_, C_0.5_, C_2_) cut off of 27.5 mg·h/L for acute rejection in kidney transplant recipients had a diagnostic sensitivity of 81.2 percent and a diagnostic specificity of 93.4 percent. The C_0_ cut off for acute rejection of 1.1 mg/L had a diagnostic sensitivity of 63.4 percent and a diagnostic specificity of 85.3 percent. In a similar case series, Pawinski et al.^43^ found that an AUC (based on C_0_, C_0.5_, C_2_) cut off of 24.1 mg·h/L for acute rejection had a diagnostic sensitivity of 77.8 percent and diagnostic specificity of 91.7 percent. A C_0_ cut off of 0.8 mg/L had a diagnostic sensitivity of 59.3 percent and diagnostic specificity of 83.3 percent. A C_max_ cut off of 5.1 mg/L had a diagnostic sensitivity of 66.7 percent and diagnostic specificity of 87.5 percent. Borrows et al.^14^ found that a median MPA C_0_ of 1.60 mg/L best differentiated between kidney transplant recipients with and without acute rejection in the first 30 days post transplant. However, no association was observed between MPA concentration and five specific acute rejection episodes that occurred after 30 days. Kiberd et al.^57^ found that the best cut off point for predicting rejection in kidney transplant recipients was an AUC (based on C_0_, C_1_, C_2_, C_4_) of 22 mg.h/L (sensitivity 82 percent, specificity 64 percent, negative predictive value 89 percent, positive predictive value 30 percent).

Graft function or other efficacy parameter. Two studies^18,106^ looked at methods of MPA monitoring and the incidence of graft function (Tables 15 and 16). The first study^18^ was a case series involving 46 stable kidney transplant recipients. Graft function was defined by creatinine clearance (severe graft dysfunction: creatinine clearance less than 20 mL/min). Patients with an MPA AUC_0–12_ cut off greater than 40 μg/mL·h had better graft function than patients with an MPA AUC_0–12_ of 40 μg/mL·h or less. Mean creatinine clearance values were 85.7 mL/min in the ‘greater than’ group and 64.5 mL/min in the ‘less than’ group (p<0.01). The authors claimed to have similar findings for an MPA predose concentration (AUC_0–2_) cut off of 1.5 μg/mL, but no data were reported. MPA AUC_0–12_ was significantly and positively correlated with creatinine clearance (r=0.52, p< 0.01), as was predose concentration (MPA AUC_0–2_) (r=0.50, p< 0.01).

Table 15 Studies showing some relationship between graft function or other efficacy parameter and method of MPA monitoring

Method of Monitoring | Study Author/Citation | Population | Treatment | Major Findings/ Comments
Full AUC (AUC_0–12_) | None | - | - | -
Limited sampling strategies - Predose (C_0_, C_min_, or C_12_) | Cattaneo^18^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day | MPA C_0_ was significantly and positively correlated with creatinine clearance (r=0.5, p< 0.01)
| Study design: Case series | Age: Mean AUC >40 μg.ml h: 31.9 +/- 9.0y, AUC <40 μg .ml h: 39 +/- 12.4y | Concomitant medications:
| Length of followup: 9 months | | Cyclosporine
| | | Prednisone
| | | Neurol
Limited sampling strategies - 2h Post (C_2_) | None | - | - | -
Limited sampling strategies - Other | Cattaneo^18^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day | MPA AUC (as predicted by C_0_, C_20min_, C_40min_, C_75min_, and C_120min_) was significantly and positively correlated with creatinine clearance (r=0.52, p< 0.01)
| Study design: Case series | Age: Mean AUC >40 μg.ml h: 31.9 +/- 9.0y, AUC <40 μg.ml h: 39 +/- 12.4y | Concomitant medications:
| Length of followup: 9 months | | Cyclosporine
| | | Prednisone
| | | Neurol

Abbreviations: AUC=Area-under-the-concentration-time curve, C_0_=Predose Trough Serum or Plasma Concentration, C_min_=Minimum Serum or Plasma Concentration, H=high,MPA=Mycophenolic Acid

Table 16 Studies showing no relationship between graft function or other efficacy parameter and method of MPA monitoring

Method of Monitoring | Study | Population | Treatment | Major Findings/ Comments
Full AUC (AUC_0–12_) | Brunet^106^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 1 g, .075 g, and 0.5 g | Although the authors report that “for the majority of the patients an inverse relationship between MPA concentrations and IMPDH activity was observed”, patients with comparable MPA AUC_0–12_ values exhibited different degrees of IMPDH inhibition (thus suggesting wide interindividual pharmacodynamic activity)
| Study design: Case control | Age: Mean 42.5 +/- 13.6y | Concomitant medications:
| Length of followup: 38.5 months (6–166 months) | Range 18–65y | Prednisone
| | | CsA
Limited sampling strategies - Predose (C_0_, C_min_, or C_12_) | Brunet^106^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 1 g, .075 g, and 0.5 g | Although the authors report that “for the majority of the patients an inverse relationship between MPA concentrations and IMPDH activity was observed”, patients with comparable MPA predose concentrations exhibited different degrees of IMPDH inhibition (thus suggesting wide interindividual pharmacodynamic activity)
| Study design: Case control | Age: Mean 42.5 +/- 13.6y | Concomitant medications:
| Length of followup: 38.5 months (6–166 months) | Range 18–65y | Prednisone
| | | CsA
Limited sampling strategies - 2h Post (C_2_) | None | - | - | -
Limited sampling strategies- Other | None | - | - | -

Abbreviations: AUC=Area-under-the-concentration-time curve, C_0_=Predose Trough Serum or Plasma Concentration, C_min_=Minimum Serum or Plasma Concentration, CsA=Cyclosporin A, IMPDH=Inosine 5′-Monophosphate Dehydrogenase, MPA=Mycophenolic Acid, y=Years

A case control study^106^ of 27 stable kidney transplant patients looked at the correlation of MPA AUC_0–12_, C_min_, and C_max_ with IMPDH (Inosine 5′-Monophosphate Dehydrogenase) activity, a direct pharmacodynamic parameter of MPA. Although the authors reported that “for the majority of the patients an inverse relationship between MPA concentrations and IMPDH activity was observed”, patients with comparable MPA AUC_0–12_, C_min_, and C_max_ values exhibited different degrees of IMPDH inhibition, which suggests wide interindividual pharmacodynamic activity. Furthermore, in MPA-treated patients, baseline IMPDH differences may lead to differences in outcome.

Adverse events. Four studies showed that full AUC (AUC_0–12_) is associated with adverse events. One of these studies was a non randomized controlled trial^31^ and the three others were case series.^33,^,^36,46^ There were 18 positive studies involving predose concentrations (predose, C_0_, C_min_, or C_12_): one was an RCT,^68^ three were prospective cohort studies,^39^–^41^ and 14 were case series.^14,^,^16,^,^33,^,^36,^,^45,^,^48,^,^56,^,^61,69^–^74^ Five studies found other limited sampling strategies to be related to adverse events: one was an RCT evaluating C_0_, C_1_, C_3_, and C_6_^65^ and four were case series (one of C_40min_,^66^ one of C_0_, C_1_, C_3_, and C_6_,^59^ one of both C_30min_ and C_60min_,^59^ and one of C_30min_^67^). No studies found C_2_ to be a significant predictor of adverse events (Tables 17–20).

Table 17 Studies showing some relationship between adverse events and method of MPA monitoring

Study | Population | Treatment | Major Findings/ Comments
Filler^46^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BID | Weak supportive data: Other than one patient with a high MPA AUC_0–12_ (data not provided) who experienced abdominal pain and diarrhea, no patient experienced adverse events
Study design: Case series | Age: Mean 17.2 +/- 4.2 SD y | Concomitant medications:
Length of followup: 6.2 +/- 2.7 y (2.3–11.8) | | Cyclosporine
| | Steroids
Kuypers^36^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 0.5 g BID or 1 g BID | Same study as ^52^ (Prospective Cohort)
Study design: Case series | Age: Median 51.5y | Concomitant medications: | From 3 months on, patients with anemia or leuopenia had significantly higher MPA AUC compared with those without (p≤ 0.04).
Length of followup: 12 months | | Tacrolimus | Note that a full AUC_0–12_ was obtained on Day 7, a 2-h AUC at week 6, and a 4-h AUC at months 3, 6, and 12 (the 2- and 4-h AUCs were used to predict AUC_0–12_)
| | Methylprednisolone
| | Daclizumab
Mourad^33^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 500 mg BID + adjustment for side effects | Significant differences were observed in AUC (48.38 vs. 36.04 mg·h/L, p=0.0006), and dose-normalized AUC (0.16 vs. 0.12 (mg·h/L)/(mg/m^2^) between patients (samples) with side effects and those without. MPA AUC cut off of 37.6 mg·h/L for toxicity had a diagnostic sensitivity of 83.3% and a diagnostic specificity of 59.6%). ROC curves were not significantly different between these parameters
Study design: Case series | Age: Range 32–68y | Concomitant medications:
Length of followup: 3 months | | Tacrolimus
| | Corticosteroids
Takahashi^31^ 1995 | Organ transplanted: Kidney (Renal) | Dose: 1000, 2000, or 3000 mg/d | Two patients (who had two of the 3 highest MPA AUC values of > 90 mg/h/L) developed CMV infection. Although other adverse events were reported, no attempts were made to relate them to MPA AUC
Study design: Non randomized controlled trial | Age: Inclusion requirement ≥16y | Concomitant medications:
Length of followup: 12 weeks | 1000 mg/day: Mean 37.7 +/- 6.3y | Cyclosporine
| 2000 mg/day: Mean 38.5 +/- 12.2y | Steroids (no description)
| 3000 mg/day: Mean 41.0 +/- 10.3y

Abbreviations: AUC=Area-under-the-concentration-time curve, BID=Twice Daily, CMV=Cytomegalovirus, ROC= Receiver Operating Characteristic, MPA=Mycophenolic Acid SD=Standard Deviance, Y=years

Table 18 Studies showing some relationship between adverse events and method of MPA monitoring. Limited sampling strategies - Predose (C_0_, C_min_, or C_12_)

Study | Population | Treatment | Major Findings/ Comments
Braun^39^ 1998 | Organ transplanted: Kidney (Renal) Liver | Dose: 30–40 mg/kg/day | Weak supporting data: All 6 patients with liver graft rejection had low MPA predose concentrations (<1 mg/L) and severe diarrhea. Two renal transplant patients had relatively high MPA concentrations > 3 mg/L that “seemed to be associated with CMV infection” (but no data were provided)
Study design: Prospective Cohort | Age: Not reported | Concomitant medications:
Length of followup: median 280 d (19–585) | | Tacrolimus
Brusa^41^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 250 to 1000 mg/day BID | Very weak supporting data for therapeutic drug monitoring: Of 7 patients with MPA predose concentrations > 4 μg/mL, 3 had serious adverse events (thrombocytopenia, leucopenia, CMV and creatinemia)
Study design: Prospective Cohort | Age: Range 18 patients: 13–58y; 5 patients: 35–56y | Concomitant medications:
Length of followup: >12 months | | Cyclosporine
| | Corticosteroids
Borrows^14^ 2006 | Organ transplanted: Kidney (Renal) | Dose: 750 mg – 2 g/day | Median predose concentration of 2.6, 2.75. 2.40, and 3.20 mg/L best discrimated between patients with and without anemia, leucopenia, diarrhea, and viral infection, respectively
Study design: Case series | Age: Mean 46 +/- 9y | Concomitant medications:
Length of followup: 38 months median 25 months range 13–38 months | Range 37 – 55y | Tacrolimus
| | Methylprednisolone
| | Prednisone
Borrows^69^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 250–1500 mg/day corrected for body weight | Infective diarrhea was associated with lower MPA concentrations (p<0.001). MPA concentrations at onset of MMF-related diarrhea were higher than those of patients not experiencing diarrhea (3.1 mg/L vs. 2.0 mg/L, p<0.001)
Study design: Case series | Age: Mean 46 +/- 9y | Concomitant medications:
Length of followup: 30 months median 19 months range 6 – 30 months | Range 37–55y | Tacrolimus
| | Methylprednisolone
| | Prednisone
Filler^73^ 1998 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BID reduced to 320 mg/m^2^/day over 7 weeks | Except for one severe case of diarrhea, no patient developed diarrhea at an MPA predose concentration < 5 mg/L.
Study design: Case series | Age: Mean 15.8 +/- 1.6y | Concomitant medications:
Length of followup: range 49 to 503 days, mean 282 days | Range 13 – 18 y | Tacrolimus
| | Methylprednisolone

Abbreviations: AUC=Area-under-the-concentration-time curve, AZA=Azathioprine, BID=Twice Daily, C_0_=Predose Trough Serum or Plasma Concentration, C_min_=Minimum Serum or Plasma Concentration, CMV=Cytomegalovirus, CsA=Cyclosporin A, GI= Gastrointestinal, Hb=Haemoglobin, MMF=Mycophenolate Mofetil, MPA=Mycophenolic Acid, NR= Not Reported, RCT=Randomized Controlled Trial, ROC= Receiver Operating Characteristic, RR=Relative Risk, TAC=Tacrolimus, y=Years

Table 19 Studies showing some relationship between adverse events and method of MPA monitoring. Limited sampling strategies - 2h Post (C_2_)

Study | Population | Treatment | Major Findings/ Comments
No studies addressed this question | - | - | -

Table 20 Studies showing some relationship between adverse events and method of MPA monitoring. Limited sampling strategies - Other

Study | Population | Treatment | Major Findings/ Comments
Brunet^66^ 2006 | Organ transplanted: Liver | Dose: 1 g BID | No significant correlation was found between adverse events and MPA C_0_, Cmax, or AUC_0–12_, except for patients w/ GI adverse events (diarrhea and/or nausea and vomiting) had higher C_40min_ than those without these side effects (22.9 mg/L vs. 7.4 mg/L, p=0.001)
Study design: Case series | Age: Range 29 – 66y | Concomitant medications:
Length of followup: 6 months | | Tacrolimus
| | Methylprednisolone
| | Daclizumab
Mourad^67^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Of C_0_, C_30min_, and AUC, C_30min_ was the only significant discriminator between those with and without side effects (32.99 vs. 7.45 mg/L, p<0.0001). The authors speculated that the high MPA C_30min_ values (at a fixed 2 g/day MMF dose) may explain the occurrence of adverse events in patients with MPA AUCs within the “therapeutic range” and recommend that MMF daily oral dose be divided into more than two divided doses to prevent early toxicity
Study design: Case series | Age: Mean 43y | Concomitant medications:
Length of followup: 3 months | Range 16–67y | Cyclosporine
| | Anti-thymocyte globulin
Mourad^33^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 500 mg BID + adjustment for side effects | Significant differences were observed in C_30min_ (10.47 vs. 7.66 mg/L, p=0.0091) and C_60min_ (9.67 vs. 5.83 mg/L, p=-.0002) between patients (samples) with side effects and those without.
Study design: Case series | Age: Range 32–68y | Concomitant medications: | MPA C_60min_ cut off of 8.09 mg/L for toxicity had a diagnostic sensitivity of 77.8% and a diagnostic specificity of 67.4%; ROC curves were not significantly different between C_0_, C_60min_, and AUC
Length of study design: 3 months | | Tacrolimus
| | Corticosteroids
Mudge^65^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Group w/toxicity: MPA AUC (as predicted by LSS of C_0_, C_1_, C_3_, and C_6_) = 39.3+-12.0 mg/h/L; Group w/o toxicity: 31.7+-7.9 mg/h/L p-value (gr. 1 vs gr. 2): p < 0.05; MPA AUC
Study design: RCT | Age: Mean 45.2 +/- 13.2y | Concomitant medications:
Length of followup: July 2002 – Feb 2003 | | Cyclosporine
| | Tacrolimus
| | Prednisone
Pillans^59^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day | Patients with GI adverse events (n=4) had significantly lower MPA AUC (as predicted by a LSS of C_0_, C_1_, C_3_, and C_6_) compared with patients without GI adverse events (23.7 vs. 33.2 mg.h/L, p=0.04). This paradoxical finding may suggest poor absorption and contribute to local GI effects. (Three of the 4 patients with GI adverse events also experienced acute rejection)
Study design: Case series | Age: Range 21–65y | Concomitant medications:
Length of followup: 1 month | | Cyclosporine
| | Prednisone

Abbreviations: AUC=Area-under-the-concentration-time curve, BID=Twice Daily, C_0_=Predose Trough Serum or Plasma Concentration, GI=Gastrointestinal, LSS=Limited Sampling Strategy, MMF=Mycophenolate Mofetil, MPA=Mycophenolic Acid, RCT=Randomized Controlled Trial, ROC= Receiver Operating Characteristic, y=Years

Eleven studies showed that full AUC (AUC_0–12_) is not associated with adverse events. Two of these studies (three reports) were randomized controlled trials,^11,^,^12,29^ two were prospective cohort studies,^35,52^ and seven were case series.^17,^,^26,^,^32,^,^36,^,^37,^,^66,67^ There were 24 negative studies of predose (C_0_, C_min_, or C_12_): three (four reports) were RCTs,^11,^,^12,^,^25,75^ one was a non randomized controlled trial,^49^ two were prospective cohort studies,^20,52^ one was a case control study,^54^ two were retrospective cohort studies,^22,42^ and 15 were case series (Tables 21 to 24 ).^14,^,^15,^,^17,^,^18,^,^26,^,^36,^,^37,^,^47,^,^57,^,^62,^,^64,^,^66,^,^67,^,^72,76^

Table 21 Studies showing no relationship between adverse events and method of MPA monitoring

Study | Population | Treatment | Major Findings/Comments
Brunet^66^ 2006 | Organ transplanted: Liver | Dose: 1 g twice a day | No significant correlation was found between adverse events and AUC
Study design: Case series | Age: Range 29 – 66y | Concomitant medications:
Length of followup: 6 months | | Tacrolimus
| | Methylprednisolone
| | Daclizumab
Hale^11^ 1998 | Organ transplanted: Kidney (Renal) | Dose: | P value between each specified adverse event (diarrhea, nausea, leucopenia, CMV, urinary tract infection and abdominal pain) vs. MPA AUC was not significant (p>0.05). However, the risk of diarrhea and the risk of premature study withdrawal due to adverse events were both significantly related to mean MMF dose
Study design: RCT | Age: Inclusion requirement > 18 y | L: 0.45 g BID then adjusted
Length of followup: 20 weeks | Range: | I: 0.95 g BID then adjusted
| L: 47.8 +/- 11.5 y, | H: 1.7 g BID then adjusted
| I: 46.9 +/- 13.8y, | Concomitant medications:
| H: 50.6 +/- 10.5y | Cyclosporine
| | Corticosteroids
Kuypers^36^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 0.5 g BID or 1 g BID | Same study as ^52^ (Prospective Cohort)
Study design: Case series | Age: Median 51.5y | Concomitant medications: | MPA AUC was not significantly different in patients with and without infection. MPA AUC also was not significantly higher in patients with diarrhea compared with those without
Length of followup: 12 months | | Tacrolimus
| | Methylprednisolone
| | Daclizumab
Kuypers^52^ 2003 | Organ transplanted: Kidney (Renal) | Dose: 1 g/day or 2 g/day | same study as ^36^ (Case series)
Study design: Prospective Cohort | Age: Median 51.5y | Concomitant medications: | Diarrhea was not significantly related to MPA AUC
Length of followup: 12 months | | Methylprednisolone
| | Tacrolimus
| | Daclizumab (32 patients)
Lu^29^ 2005 | Organ transplanted: Kidney (Renal) | Dose: mean 58.0 +/- 10.0 kg | There was no significant difference in rate of infection between patients with MPA AUC > 60 μg·h/mL vs. < 60 μg·h/mL.
Study design: Non randomized Clinical Trial | Age: Mean 40.0 +/- 12.0y | Concomitant medications:
Length of followup: NR | | Cyclosporine
| | Prednisone
| | Tacrolimus
Mourad^67^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Mean MPA AUC was significantly higher in patients who experienced adverse events compared to those with uneventful outcomes (52.1 vs. 39.8 mg·h/L, p=0.0005). AUC was not a significant discriminator between those with and without side effects
Study design: Case series | Age: Mean 43y | Concomitant medications:
Length of followup: 3 months | Range 16–67y | Cyclosporine
| | Anti-thymocyte globulin
Mourad^37^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Mean MPA predose concentrations were not significantly different for those experiencing MMF toxicity (3.1 vs. 2.2 mg/L, p>0.05) compared to those experiencing neither rejection nor adverse events. MPA AUC data were similar with 15.5, 72.7, and 42.1 mg·h/L associated with rejection, MMF toxicity, and neither rejection nor adverse events, respectively (p value not provided)
Study design: Case series | Age: Mean 46y | Concomitant medications:
Length of followup: 12 weeks | Range 33–57y | Cyclosporine
| | Prednisolone
Satoh^35^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 1.0 – 2 g/day | MPA AUC was not significantly different in patients with viral infections compared to those without (61.5 vs. 50.4 μg·h/mL, respectively)
Study design: Prospective Cohort | Age: Mean AZA: 37.9 +/- 11.5y | Concomitant medications:
Length of followup: 28 days | MMF: 44.3 +/- 11.6y | Tacrolimus
| | Methylprednisolone
| | Prednisone
Sumethkul^32^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 720 mg BID | Only very weak inferential evidence as purpose of study was to assess delivery of MPA by ECMPS and not to correlate MPA measurements with health outcomes: 2 patients with a AUC_0–12_ for MPA 31 and 125 mg·h/L had less diarrhea and 1 patient needed reduction of ECMPS dosage
Study design: Case series | Age: Mean 39 +/- 9y | Concomitant medications:
Length of followup: 3–8 months | | Cyclosporine
| | Prednisone
van Gelder^12^ 1999 | Organ transplanted: Kidney (Renal) | Dose: | The relation between premature study withdrawal due to adverse events and median ln MPA AUC was not statistically significant (p=0.434). Posthoc analysis showed that only the premature withdrawal due to GI (and not other) adverse events was significantly related to MMF dose. This suggests that high local, non-systemic, drug concentrations, may be responsible for the GI adverse events. The authors clarify that statistical significance is lost when only the first 3 predose concentrations are used in the logistic regression analysis and thus caution against making dosage adjustments on a limited number of predose concentrations. Note that the first 3 assessments were of full 12h AUCs whereas the later 6 assessments were of AUC_0–12_ (as predicted by LSS of C_0_, C_20min_, C_40min_, C_75min,2h_)
Study design: RCT | Age: Range L: 47.8 +/- 11.5y; I: 46.9 +/- 13.8y; H: 50.6 +/- 10.5y | L: 16.1 ug hr/ml
Length of followup: 6 months | | I: 32.2 ug hr/ml
| | H: 60.6 ug hr/ml
| | Concomitant medications:
| | Cyclosporine
| | Prednisone
| | Corticosteroids
Weber^26^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BID to a maximum of 2 g/day | There was no significant association between AUC and incidence of adverse events (leucopenia, infections, diarrhea, anemia, or thrombocytopenia)
Study design: Case series | Age: Mean 11.8y | Concomitant medications:
Length of followup: 6 months | Range 3.2 – 16.0y | Cyclosporine A
| | Methylprednisolone
Weber^17^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BID up to 2 g/day max | There was no significant association between AUC and incidence of adverse events (leucopenia, infections, diarrhea, vomiting, or abdominal pain). [Note that free MPA C_max_ and free MPA AUC were able to discriminate between patients with or without infections and/or leukemia]
Study design: Case series | Age: Range 2.2 – 17.8y | Concomitant medications:
Length of followup: 6 months | | Cyclosporine A
| | Methylprednisolone

Abbreviations: AUC=Area-under-the-concentration-time curve, AZA=Azathioprine, BID=Twice Daily, C_0_=Predose Trough Serum or Plasma Concentration, C_max_=Maximum Serum or Plasma Concentration, CMV=Cytomegalovirus, ECMPS=Enteric-Coated Mycophenolate Sodium, GI=Gastrointestinal, H=High, I=Intermediate, L=Low, LSS=Limited Sampling Strategy, MF=Mycophenolate Mofetil, MPA=Mycophenolic Acid, NR=Not Reported, RCT=Randomized Controlled Trial, y=Years

Table 22 Studies showing no relationship between adverse events and method of MPA monitoring. Limited sampling strategies - Predose (C_0_, C_min_, or C_12_)

Study | Population | Treatment | Major Findings/Comments
Behrend^25^ 1997 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day or 3 g/day; dose per body weight was 22 to 54 mg/Kg; mean 83 mg/kg + - 8.4 body weight | Very very weak supportive data: The authors state that “there is no clearcut relationship between plasma concentrations and rejection, adverse events, and infections” but provide no data. Also, they state that interindividual variability in MPA predose (or C_0_ or predose) concentrations is “by far greater than the correlation to ...dose...” but do not provide specific data
Study design: RCT | Age: Not reported | Concomitant medications:
Length of followup: at least 1 year | | Cyclosporine
| | Corticosteroids
Bilbao^62^ 2006 | Organ transplanted: Liver | Dose: Initial dose of 500 mg/12h; reaching dose of 1 g each 12h for 2 weeks. | Although adverse events (leukopenia, diarrhea) were reported, no attempts were made to relate these to MPA predose (or C_0_ or predose) concentrations. Dose adjustments were based on tolerability and adverse events and not on predose concentrations although they “tried to avoid concentrations over 4 ng/mL”
Study design: Case series | Age: Mean 59 +/- 6y | Concomitant medications:
Length of followup: mean 39 + - 20 months; range 3 to 72 months. | | Cyclosporine (neoral)
| | Tacrolimus
Borrows^14^ 2006 | Organ transplanted: Kidney (Renal) | Dose: 750 mg – 2 g/day | No association was seen between MPA concentration and platelet count. No association was seen between MPA concentration and the development of bacterial infection
Study design: Case series | Age: Mean 46 +/- 9y | Concomitant medications:
Length of followup: minimum of 12 months median 25 months range 13–38 months | Range 37–55y | Tacrolimus
| | Methylprednisolone
| | Prednisone
| | Corticosteroids
| | Ganciclovir (3 months)
| | Co-Trimoxazole (6 months)
| | Isoniazid and pyridoxine (Indo-Asians and those with previous TB)
| | Basilizimab or Daclizumab (79 patients)
Brunet^66^ 2006 | Organ transplanted: Liver | Dose: 1 g twice a day | No significant correlation was found between adverse events and MPA C_0_
Study design: Case series | Age: Range 29–66y | Concomitant medications:
Length of followup: 6 months | | Tacrolimus Methylprednisolone
| | Daclizumab
Cattaneo^18^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day | Total MPA predose concentration did not correlate significantly with red blood cell or leukocyte count (but free MPA fraction correlated negatively and significantly)
Study design: Case series | Age: Mean AUC>40 ug·ml h: 31.9 +/- 9.0y AUC<40 ug·ml h: 39 +/- 12.4y; Range 19–61y | Concomitant medications:
Length of followup: 9months | | Cyclosporine
| | Prednisone
| | CSA Neoral
Deierhoi^75^ 1993 | Organ transplanted: Kidney (Renal) | Dose: phase I: 1500 – 3000 mg/day rescue: 2000 mg/day and 3000–3500 mg/day if no response in first week to 2000 mg | Authors stated that “there was no clear cut correlation between serum concentrations [C_max_ and trough] and the occurrence of side effects or rejection episodes”, but no data were given
Study design: RCT | Age: Inclusion requirement phase I: older than 18y, rescue: older than 16y | Concomitant medications:
Length of followup: phase I trial: mean 26 months range 22 – 28 months rescue: mean 20 months range 16 – 24 months | | Phase I:
| | Minnesota antilymphocyte globulin(MALG)
| | Prednisone
| | Methylprednisolone
| | Cyclosporine
| | Rescue:
| | Corticosteroids
| | Cyclosporine
Hale^11^ 1998 | Organ transplanted: Kidney (Renal) | Dose: | P values between each specified adverse event (diarrhea, nausea, CMV, urinary tract infection and abdominal pain) vs. MPA C_0_ was not significant (p>0.05)
Study design: RCT | Age: Inclusion requirement > 18y | L: 0.45 g BID then adjusted
Length of followup: 20 weeks | Range: | I: 0.95 g BID then adjusted
| L: 47.8 +/- 11.5 y, | H: 1.7g BID then adjusted
| I: 46.9 +/- 13.8y, | Concomitant medications:
| H: 50.6 +/- 10.5y | Cyclosporine
| | Corticosteroids
Kuriata - Kordek^54^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 2.0 g/day | No significant difference was observed between patients with or without leucopenia during the 1 year followup in C_0_
Study design: Case control | Age: Inclusion requirement group I: 38.12 +/- 9.5y, group II: 38.52 +/- 9.21y | Concomitant medications:
Length of followup: 12 months | | Cyclosporine
| | Prednisone
Okamoto^49^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 25 mg/kg initially, then adjusted afterwards | MPA predose concentration was not significantly different in patients with and without adverse events
Study design: Non randomized controlled trial | Age: Mean 38 +/- 14 y | Concomitant medications:
Length of followup: NR | | Cyclosporine n=35
| | Tacrolimusn=32
Kiberd^57^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day fixed | MPA C_0_, did not significantly predict toxicity (p=0.90)
Study design: Case series | Age: Mean 48 +/- 13y | Concomitant medications:
Length of followup: 3 months | | Prednisone
| | Neoral
Krumme^47^ 1998 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Incidences of CMV infection and urinary tract infection were not significantly different in patients with and without rejection, but no data were provided on a relation between MPA predose concentrations and adverse events
Study design: Case series | Age: Range 46 +/-11y | Concomitant medications:
Length of followup: 2 months | | Cyclosporine
| | Methylprednisolone
Kuypers^36^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 0.5 g BID or 1 g BID | Same study as ^52^ (Prospective Cohort)
Study design: Case series | Age: Mean median 51.5y | Concomitant medications: | MPA C_0_ was not significantly higher in patients with diarrhea compared with those without
Length of followup: 12 months | | Tacrolimus
| | Methylprednisolone
| | Daclizumab
Kuypers^15^ 2003 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Predose MPA concentrations (C_0_) were not significantly different in patients with or without drug-related adverse events. The authors recommend that “A large randomized comparative trial examining the usefulness of frequent, more extensive pharmacokinetic measurements like area under the curve for MPA and its metabolites, is mandatory to answer the question of the necessity for routine therapeutic drug monitoring for mycophenolate mofetil in renal transplantation.”
Study design: Case series | Age: Mean 49.4 +/- 13.1y | Concomitant medications:
Length of followup: 12 months | | Methylprednisolone
| | Tacrolimus
| | Daclizumab
Kuypers^52^ 2003 | Organ transplanted: Kidney (Renal) | Dose: 1 g/day or 2 g/day | Same study as ^36^ (Case series)
Study design: Prospective Cohort | Age: Mean 51.5y | Concomitant medications: | Diarrhea was not significantly related to MPA C_0_. The time course of MPA exposure (i.e., AUC_0–12_) was related more to MMF dose than to MPA predose concentrations. That is, MPA AUC_0–12_ increased by ~40% in the first 6 weeks post-transplant in the 2-g MMF group, but by only 17% in the 1-g MMF group. At 3 months post-transplant, the 2-g group's MPA AUC_0–12_ declined minimally whereas the 1-g group's AUC_0–12_ decreased to its nadir. In both groups, MPA AUC_0–12_ returned to baseline values. Thus, the authors suggest that using MPA predose concentrations in routine therapeutic drug monitoring may be misleading regarding efficacy or toxicity
Length of followup: 12 months | | Methylprednisolone
| | Tacrolimus
| | Daclizumab (31 patients)
Merkel^22^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 0.5 – 1.0 g BID | There was no correlation between hemoglobin concentrations and MPA predose concentration (p value not provided)
Study design: Retrospective Cohort | Age: Mean 44 +/- 13.6y | Concomitant medications:
Length of followup: 16 months, mean 5.7 months | Range 13–63y | Cyclosporine
| | Prednisone
| | Corticosteroids
Mourad^67^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | There was no significant difference (p-0.0635) in mean MPA C_0_ (predose or trough) between those with adverse events and those without. C_0_ was nor a significant discriminator between those with and without side effects
Study design: v Case series | Age: Mean 43y | Concomitant medications:
Length of followup: 3 months | Range 16–67y | Cyclosporine
| | Anti-thymocyte globulin
| | Steroids
Mourad^37^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 1g BID | Mean MPA predose concentrations were not significantly different for those experiencing MMF toxicity (3.1 vs. 2.2 mg/L, p>0.05) compared to those experiencing neither rejection nor adverse events. MPA AUC data were similar with 15.5, 72.7, and 42.1 mg·h/L associated with rejection, MMF toxicity, and neither rejection nor adverse events, respectively (p value not provided)
Study design: Case series | Age: Mean 46y | Concomitant medications:
Length of followup: 12 weeks | Range 33–57y | Cyclosporine
| | Prednisolone
Pawinski^64^ 2006 | Organ transplanted: Kidney (Renal) | Dose: 0.5 – 2 g/day | No correlation was found between MPA predose and wbc count or hematocrit values
Study design: Case series | Age: Range 17–62y | Concomitant medications:
Length of followup: 3 months | | Cyclosporine
| | Tacrolimus
| | Prednisone
Shaw^20^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Weak supportive data: The authors stated “The occurrence of diarrhea was not associated with high concentrations of either total or free MPA AUC, predose, or MPAG predose values”, but did not provide specific data
Study design: Prospective Cohort | Age: Range 47 +/-9.7y | Concomitant medications:
Length of followup: 90 days | | Neoral Steriods
Sugioka^76^ 2006 | Organ transplanted: Kidney (Renal) | Dose: MPA group: 250 or 1750 mg/day | No significant differences were observed in predose concentration between patients with and without adverse events of or diarrhea
Study design: Case series | Age: Range MPA group: 7 – 69y, PSL group: 11 – 66y | Concomitant medications:
Length of followup: 28 days | | Cyclosporine
| | Tacrolimus
van Besouw^72^ 1999 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day - 1 g/day | MPA predose concentration was not correlated with the leukocyte counts (Spearman r= - 0.13, p=0.27)
Study design: Case series | Age: Not reported | Concomitant medications:
Length of followup: 8 months | | Prednisone
van Gelder^12^ 1999 | Organ transplanted: Kidney (Renal) | Dose: | The relation between premature study withdrawal due to adverse events and median ln C_0_ was not statistically significant (p=0.512)
Study design: RCT | Age: Range L: 47.8 +/- 11.5y; I: 46.9 +/- 13.8y; H: 50.6 +/- 10.5y | L: 16.1 ug hr/ml
Length of followup: 6 months | | I: 32.2 ug hr/ml
| | H: 60.6 ug hr/ml
| | Concomitant medications:
| | Cyclosporine
| | Prednisone
| | Corticosteroids
Weber^26^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ twice a day to a maximum of 2 g/day | There was no significant association between C_0_ and incidence of adverse events (leucopenia, infections, diarrhea, anemia, or thrombocytopenia)
Study design: Case series | Age: Mean 11.8y | Concomitant medications:
Length of followup: 6 months | Range 3.2 – 16.0y | Cyclosporine A
| | Methylprednisolone
Weber^17^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BSA twice a day up to 2 g/day max | There was no significant association between C_0_ and incidence of adverse events (leucopenia, infections, diarrhea, vomiting, or abdominal pain)
Study design: Case series | Age: Range 2.2 – 17.8y | Concomitant medications:
Length of followup: 6 months | | Cyclosporine A
| | Methylprednisolone
Yamani^42^ 2000 | Organ transplanted: Heart (Cardiac) | Dose: 2 g/day | There was no significant difference in mean total white blood cell count, total lymphocyte count, or percentage lymphocytes in MPA predose concentration groups of < 2, 2–5, and > 4 mg/L)
Study design: Retrospective Cohort | Age: Mean 36 +/- 14y | Concomitant medications:
Length of followup: 179 +/- 52 days | | Cyclosporine
| | Tacrolimus
| | Prednisone

Abbreviations: AUC=Area-under-the-concentration-time curve, BID=Twice Daily, BSA=Body Surface Area, C_0_=Predose Trough Serum or Plasma Concentration, C_max_=Maximum Serum or Plasma Concentration, CMV=Cytomegalovirus, MMF=Mycophenolate Mofetil, MPA=Mycophenolic Acid, MPAG=Mycophenolic Acid Glucuronide, NR=Not Reported, PSL=Predonisolone, RCT=Randomized Controlled Trial, TB=Tuberculosis, y=Years

Table 23 Studies showing no relationship between adverse events and method of MPA monitoring. Limited sampling strategies - 2h Post (C_2_)

Study | Population | Treatment | Major Findings/Comments
Kiberd^57^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day fixed | MPA C_2_ did not significantly predict toxicity (p=0.90)
Study design: Case series | Age: Mean 48 +/- 13y | Concomitant medications:
Length of followup: 3 months | | Prednisone
| | Neoral
Kuriata - Kordek^54^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 2.0 g/day | No significant difference was observed between patients with or without during the 1-year followup in C_2_
Study design: Case control | Age: Inclusion requirement | Concomitant medications:
Length of followup: 12 months | group I: 38.12 +/- 9.5y, | Cyclosporine
| group II: 38.52 +/- 9.21y | Prednisone

Abbreviations: MPA=Mycophenolic Acid, y=Years

Table 24 Studies showing no relationship between adverse events and method of MPA monitoring. Limited sampling strategies - Other

Study | Population | Treatment | Major Findings/Comments
Atcheson^13^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Patients who experienced one or more hematological adverse events (thrombocytopenia, leucopenia, or infection) did not have significantly higher MPA AUC_0–6_ (i.e., C_0_, C_1_, C_3_, and C_6_) values compared to patients without these adverse events (p=0.18). The latter may suggest that MPA's GI adverse events may be related to local drug concentrations. (Note that free MPA AUC was a better predictor of hematological or infectious adverse events compared with total MPA AUC.)
Study design: Prospective Cohort | Age: Mean 44.3 +/- 13.1 y | Concomitant medications:
Length of followup: NR | | Cyclosporine n=32
| | Tacrolimus n=10
| | Simulect
| | Diltiazem
| | Prednisolone
Brunet^66^ 2006 | Organ transplanted: Liver | Dose: 1 g BID | No significant correlation was found between adverse events and MPA C_max_ except for patients w/GI adverse events (diarrhea and/or nausea and vomiting)
Study design: Case series | Age: Range 29 – 66y | Concomitant medications:
Length of followup: 6 months | | Tacrolimus
| | Methylprednisolone
| | Daclizumab
Deierhoi^75^ 1993 | Organ transplanted: Kidney (Renal) | Dose: phase I: 1500 – 3000 mg/day rescue: 2000 mg/day and 3000–3500 mg/day if no response in first week to 2000 mg | Authors stated that “there was no clear cut correlation between serum levels [C_max_ and trough] and the occurrence of side effects or rejection episodes”, but no data were given
Study design: RCT | Age: Inclusion requirement | Concomitant medications:
Length of followup: phase I trial: mean 26 months range 22 – 28 months rescue: mean 20 months range 16 – 24 months | phase I: older than 18y, rescue: older than 16y | Phase I:
| | Minnesota antilymphocyte globulin(MALG)
| | Prednisone
| | Methylprednisolone
| | Cyclosporine
| | Rescue:
| | Corticosteroids
| | Cyclosporine
Hale^11^ 1998 | Organ transplanted: Kidney (Renal) | Dose: | P values between each specified adverse event (diarrhea, nausea, , CMV, urinary tract infection and abdominal pain) vs. Cmax was not significant (p>0.05)
Study design: RCT | Age: Inclusion requirement > 18 y | L: 0.45 g BID then adjusted
Length of followup: 20 weeks | Range: | I: 0.95 g BID then adjusted
| L: 47.8 +/- 11.5 y, | H: 1.7 g BID then adjusted
| I: 46.9 +/- 13.8y, | Concomitant medications:
| H: 50.6 +/- 10.5y | Cyclosporine
| | Corticosteroids
Heller^77^ 2007 | Organ transplanted: Kidney (Renal) | Dose: Fixed dose group: 1 g BID, Concentration-controlled group: target concentration of 30–60 mg*h/L | MPA AUC, as predicted by LSS of C_0_, C_0.5_, and C_2_, was not significantly different between patients who suffered an episoide of diarrhea versus those who did not.
Study design: Prospective cohort | Age: Mean 53.4y | Concomitant medications:
Length of followup: 12 months | | Cyclosporine
| | Tacrolimus
Kaplan^21^ 1999 | Organ transplanted: Kidney (Renal) | Dose: 1.75 +/- 0.3 g/day | No p values were given, but there did not appear to be a relation between MMF dose and adverse events nor between MPA AUC and adverse events. MPA AUC was predicted by LSS of C_0_, C_20min_, C_40min_, C_75min_, and C_120min_. [Leucopenia occurred in 4 patients, 3 of whom had the highest free MPA AUC values (5.07, 2.26, and 1.92 μg.h/mL) and one who had the fifth highest free MPA AUC (1.69 μg.h/mL); a patient with the 4^th^ highest free MPA AUC (1.82 μg.h/mL) did not experience. Abdominal pain, diarrhea and CMV occurrences were infrequent and thus could not be correlated to free MPA AUC.]
Study design: Case series | Age: Range chronic renal subjects 46.7 +/- 9.2y; | Concomitant medications:
Length of followup: >2 weeks | renal patients without chronic insufficiency 43.3 +/- 8/6y | Not reported
Kiberd^57^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 2 g/day fixed | MPA AUC, as predicted by LSS of C_0_, C_1_, C_2_, and C_4_, did not significantly predict toxicity (p=0.29)
Study design: Case series | Age: Mean 48 +/- 1 3y | Concomitant medications:
Length of followup: 3 months | | Prednisone
| | Neoral
Kuriata-Kordek^54^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 2.0g/day | No significant difference was observed between patients with or without during the 1 year followup in C_40min_, C_60min_, or C_max_
Study design: Case control | Age: Inclusion requirement | Concomitant medications:
Length of followup: 12 months | group I: 38.12 +/- 9.5y, | Cyclosporine
| group II: 38.52 +/- 9.21y | Prednisone
Kuypers^36^ 2004 | Organ transplanted: Kidney (Renal) | Dose: 0.5 g BID or 1 g BID | Same study as Kuypers^52^ (Prospective Cohort)
Study design: Case series | Age: Median 51.5y | Concomitant medications: | MPA C_max_ was not significantly higher in patients with diarrhea compared with those without
Length of followup: 12 months | | Tacrolimus
| | Methylprednisolone
| | Daclizumab
Kuypers^52^ 2003 | Organ transplanted: Kidney (Renal) | Dose: 1 g/day or 2 g/day | Same study as Kuypers^36^ (Case series)
Study design: Prospective Cohort | Age: Mean 51.5y | Concomitant medications: | Diarrhea was also not significantly related to MPA C_max_
Length of followup: 12 months | | Methylprednisolone
| | Tacrolimus
| | Davlizumab (31 patients)
Le Meur^10^ 2007-10-30 | Organ transplanted: Kidney | Fixed dose group: 1 g BID; Concentration-controlled group: Days 1–7, 1 g BID, then dose to target AUC of 40 mg*h/L | There was no significant difference (p>0.05) in incidence of adverse events (total, gastrointestinal events, anemia, leucopenia, general infections, cytomegalovirus, other viral infections, bacterial infections, or other infections) between the concentration-controlled and fixed dose groups, except for herpes infections which occurred more frequently in the concentration-controlled group (8 vs. 1 event, p<0.05). Overall, 97% and 90% of patients in the concentration-controlled and fixed dose groups, respectively, reported one (or more) adverse events.
Study design: RCT | Age: | Concomitant medications:
Length of followup: 12 months | Fixed dose group 49 +/- 13y | Cyclosporine
| Concentration-controlled group: 50 +/- 14y | Methylprednisolone
| | Basiliximab
| | Trimethoprim-sulfamethoxazole
Okamoto^49^ 2005 | Organ transplanted: Kidney (Renal) | Dose: 25 mg/kg initially, then adjusted afterwards | MPA AUC_0–9_ was not significantly different in patients with and without adverse effect
Study design: Non randomized controlled trial | Age: Mean 38 +/- 14 years | Concomitant medications:
Length of followup: NR | | Cyclosporine n=35
| | Tacrolimus n=32
Pawinski^64^ 2006 | Organ transplanted: Kidney (Renal) | Dose: 0.5 – 2 g/day | No correlation was found between MPA AUC (as predicted by LSS of C_0_, C_0.5_, and C_2_) and wbc count or hematocrit values
Study design: Case series | Age: Range 17–62y | Concomitant medications:
Length of followup: 3 months | | Cyclosporine
| | Tacrolimus
| | Prednisone
Shaw^20^ 2000 | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Weak supportive data: The authors stated “The occurrence of diarrhea was not associated with high concentrations of either total or free MPA AUC, predose, or MPAG predose values”, but did not provide specific data. (They also reported a 21% higher than average free MPA AUC in patients who had leucopenia compared with those who did not.]) MPA AUC was predicted by LSS of C_0_, C_20min_, C_40min_, C_75min_, and C_120min_.
Study design: Prospective Cohort | Age: Range 47 +/-9.7y | Concomitant medications:
Length of followup: 90 days | | Neoral Steriods
Sugioka^76^ 2006 | Organ transplanted: Kidney (Renal) | Dose: MPA group: 250 or 1750 mg/day | No significant differences were observed in AUC_0–9_ (i.e., C_0_, C_1_, C_2_, C_3_, C_4_, C_6_, and C_9_) or Cmax, between patients with and without adverse events of leucopenia or diarrhea
Study design: Case series | Age: Range MPA group: 7–69y, | Concomitant medications:
Length of followup: 28 days | PSL group: 11–66y | Cyclosporine A
| | Tacrolimus
| | Prednisone
Weber^26^ 2002 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BID to a maximum of 2 g/day | There was no significant association between C_max_, AUC_0–4_ (i.e., C_0_, C_75min_, and C_4_), or AUC_0–2_ (i.e., C_0_, C_20min_, C_40min_, C_75min_, and C_120min_) and incidence of adverse events (leucopenia, infections, diarrhea, anemia, or thrombocytopenia)
Study design: Case series | Age: Mean 11.8y | Concomitant medications:
Length of followup: 6 months | Range 3.2–6.0y | Cyclosporine A
| | Methylprednisolone
Weber^17^ 2001 | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m^2^ BID up to 2 g/day maximum | There was no significant association between C_max_, AUC_0–4_ (i.e., C_0_, C_75min_, and C_4_), or AUC_0–2_ (i.e., C_0_, C_20min_, C_40min_, C_75min_, and C_120min_) and incidence of adverse events (leucopenia, infections, diarrhea, vomiting, or abdominal pain).[Note that free MPA C_max_ and free MPA AUC_0–12_ were able to discriminate between patients with or without infections and/or leukemia]
Study design: Case series | Age: Range 2.2–17.8y | Concomitant medications:
Length of followup: 6 months | | Cyclosporine A
| | Methylprednisolone

Abbreviations: AUC=Area-under-the-concentration-time curve, BID=Twice Daily, BSA=Body Surface Area, C_0_=Predose Trough Serum or Plasma Concentration, C_max_=Maximum Serum or Plasma Concentration, CMV=Cytomegalovirus, GI=Gastrointestinal, LSS=Limited Sampling Strategy, LSS=Limited Sampling Strategy, MPA=Mycophenolic Acid, MPAG=Mycophenolic Acid Glucuronide, MPA=Mycophenolic Acid, NR= Not Reported, PSL=Prednisolone, RCT=Randomized Controlled Trial, WBC=White Blood Cells, y=Years

Two studies (a case control^54^ and a case series^57^) found C_2_ not to be a significant predictor of adverse events. Of 16 studies finding other limited sampling strategies to be unrelated to adverse events, one was a RCT directly comparing fixed dose versus targeted AUC values based on a limited sampling strategy (LSS) of C_20min_, C_1_, C_3_^10^, two were RCTs evaluating C_max_,^11,75^ one was a non randomized controlled trial of AUC_0–9_^49^, 3 were prospective cohort studies (one of C_0_, C_20min_, C_40min_, C_75min_, and C_120min,_^20^ one of C_0_, C_1_, C_3_, and C_6_^13^, and one of C_max_^52^), one was a case control study of 3 different LSSs (i.e., C_40min_, C_60min_, and C_max_),^54^ and 8 were case series (one evaluating both C_0_, C_1,_ C_2,_ C_4,_ C_6_, and C_9_ as well as C_max,_^76^ one of C_0_, C_0.5_, and C_2,_^64^ two of C_max_,^36,66^ one of C_0_, C_1_, C_2,_ and C_4,_^57^ two evaluating 3 different LSSs of C_max_, AUC_0–4_ or C_0_, C_75min_, and C_4_, and AUC_0–2_ or C_0_, C_20min_, C_40min_, C_75min_, and C_120min_,^17,26^ and another evaluating C_0_, C_20min_, C_40min_, C_75min_, and C_120min_^21^).

A secondary objective of the Le Meur et al. RCT^10^ was to compare the incidence of adverse events in the concentration-controlled versus the fixed dose groups. Overall, 97 percent and 90 percent of patients in the concentration-controlled and fixed dose groups, respectively, reported one (or more) adverse events. There was no significant difference (p>0.05) in incidence of total adverse events and specific gastrointestinal events, anemia, leucopenia, or infections between the two groups, except for herpes infections which occurred more frequently in the concentration-controlled group (8 vs. 1 event, p<0.05).^10^

The van Gelder et al.^12^ and Hale et al.^11^ RCT in kidney transplant patients compared adverse events for subjects with planned dose adjustments based on different target MPA plasma concentrations.^11,12^ They found that premature study withdrawal due to adverse events was not associated with the median natural logarithm of MPA AUC_0–12_ (p=0.434) nor the median natural logarithm of C_0_ (p=0.512). Associations between each specified adverse effect (i.e., diarrhea, nausea, leucopenia, CMV, urinary tract infection, and abdominal pain) and MPA AUC_0–12_, MPA C_max_, and MPA C_0_ were all not statistically significant (p>0.05).^11^ One explanation for the lack of statistically significant associations is that the data anlysis in the trial was undertaken before the ascertainment of total MPA concentrations over time post transplant. Median AUC was used instead, and patients with higher median AUCs tended to remain in the study longer than patients with adverse events.^6^

A case series conducted by Hubner et al.^56^ in kidney transplant recipients reported adverse events for subjects with planned dose adjustments based on MPA predose concentrations. The data showed that MPA predose concentrations for patients with adverse events were higher relative to patients without adverse events (2.13 versus 1.53 mg/L; p< 0.001). Shaw et al.^20^ evaluated two groups of kidney transplant recipients (i.e., MPA AUC-controlled versus MPA C_0_-controlled dose adjustment) and stated that the occurrence of diarrhea was not associated with high concentrations of MPA AUC, predose, or MPAG predose values. However, they did not provide quantiative data for their claim.^20^

In three case series,^14,^,^33,48^ the authors generated ROC curves to determine whether a particular PK parameter could differentiate between patients with and without adverse events. Mourad et al.^33^ found that an MPA C_0_ cut off of 3 mg/L for toxicity in kidney transplant recipients had a diagnostic sensitivity of 38.7 percent and a diagnostic specificity of 91.5 percent. An MPA C_60min_ cut off of 8.09 mg/L for toxicity had a diagnostic sensitivity of 77.8 percent and a diagnostic specificity of 67.4 percent. Lastly, an MPA AUC_0–12_ cut off of 37.6 mg·h/L for toxicity had a diagnostic sensitivity of 83.3 percent and a diagnostic specificity of 59.6 percent. The ROC curves were not statistically significantly different between these parameters.^33^ Borrows et al.^14^ found the median C_0_s that best discrimated between patients with and without the following adverse events: leucopenia (2.60 mg/L), anemia (2.75 mg/L), diarrhea (2.40 mg/L), and viral infection (3.20 mg/L). The Lu et al.^48^ ROC analysis showed significant correlations between MPA C_0_ and clinicial effects (rejection and toxicity) in kidney transplant recipients,with a dignostic sensitivity of 65.1 to 84.6 percent and specificity of 74.7 to 84.7 percent.

### Question 4. Does the Evidence for Monitoring MPA Differ by any of the Following?

Forty eight studies were included to address the six components of the key question. Study characteristics are shown in Evidence Table 1, Appendix C^*^.

#### 4a: Age

Six studies^17,^,^18,^,^23,^,^69,^,^112,122^ addressed the effect of age on MPA PK parameters in kidney transplant patients. Three of these studies included adult patients only,^18,^,^69,122^ two included pediatric patients only,^17,23^ and one compared pediatric with adult kidney transplant patients.^112^ One other study involved pediatric heart transplant patients.^55^ The findings of these studies (Table 25) are summarized below.

Table 25 Influence of age on the utility of monitoring mycophenolic acid in patients who receive a solid organ transplant

Study | Organ | n | Age | % Male | Race | Medications | Health Outcomes Reported | Results
Borrows^69^ 2005 | Kidney (Renal) | 117 | Mean: | 58.1 | White 55.6% | Tacrolimus | Infective diarrhea, patient survival, graft survival, biopsy proven acute rejection | No association between age and MPA predose concentrations
| | | 46 +/- 9y | | Indo-Asian 23.1% | Methylprednisolone
| | | Range: | | Afro-Carib 17.9% | Prednisone
| | | 37–55y | | Other 3.4%
Bunchman^23^ 2001 | Kidney (Renal) | 100 | Inclusion requirement 3 months – 18 years | 68 | 64 patients were from North America, 4 from Australia and 32 from Europe | 600 mg/m^2^ BID up to 1 g BID | Presumptive rejection, diarrhea, anemia, sepsis, leukopenia, renal function (creatinine clearances) | No associations were observed between low MPA and MPAG plasma concentrations and the incidence of acute rejection or of adverse events
| | | | | | | % rejections and adverse events by age group and AUC and Cmax
| | | | | | | Age groups:
| | | | | | | <6y
| | | | | | | 6 to 12y
| | | | | | | 12 to 18y
| | | | | | | < 2y
Cattaneo^18^ 2001 | Kidney (Renal) | 46 | Range | 63 | NR | 2 g/day | Creatinine clearance, renal function, rejection episodes, serum creatinine concentration, creatinine clearance | Patients with MPA AUC_0–12_ > 40 μg/mL.h group slightly but significantly younger than patients in the < 40 μg/mL.h group
| | | 19–61y
Dipchand^55^ 2001 | Heart (Cardiac) | 44 | Range | 61 | NR | various: 15–159 mg/kg | Rejection | Increased MPA predose concentrations were significantly associated with older children
| | | 29 d-23.5y
| | | Median 6.3y
Wang ^122^ 2007 | Kidney (Renal) | 48 | Elderly group: | 67 | Chinese | Cyclosporine | Acute rejection | MPA AUC was significantly lower in the elderly group compared to the younger adult group, while there was no significant difference in predose, peak concentrations, or peak times. AUC in the subgroup of elderly patients with severe adverse events was significantly higher than that of elderly patients without severe adverse events.
| | | 65.6 +/- 3.6y | | | MMF | Severe adverse events:
| | | Adult group: | | | Prednisone | Pneumonia, leukopenia, death
| | | 39.6 +/- 14.3y
Weber^17^ 2001 | Kidney (Renal) | 24 | Range: | 61.1 | All patients were white | Cyclosporine | Acute rejection, adverse events (leucopenia, infections) | In the first week post-transplant, but not at later PK sampling periods, low MPA AUC_0–12_ values were associated with young age
| | | 2.2 – 17.8y | | | Methylprednisolone | | MPA AUC_0–12_ and predose MPA concentrations were significantly associated with the risk of acute rejection
Weber, L^112^ 1998 | Kidney (Renal) | 28 | Children Mean | 64 | NR | Children: 600 mg/m^2^ body surface area BID | Transplant dysfunction all subjects | Mean MPA AUC_0–12_ in pediatric patients one week post-transplant was 40% higher than in adults, but comparable at three weeks.
| | | 10.7 +/- 0.72y | | | Adults: 1 g BID | | The AUC_0–12_ values of free MPA at one and three weeks did not differ between children and adults.
| | | Range | | | | | Children displayed concentration-time profiles of total and free MPA after oral administration of 600 mg/m^2^ body surface area twice daily that, in general, were comparable to the profiles of adults receiving 1,000 mg MMF twice daily
| | | 5.9 – 15.3y
| | | Adults Mean
| | | 45.9 +/- 4.1y
| | | Range
| | | 20.1 – 59.2y

Abbreviations: AUC=Area-under-the-concentration-time curve, BID=Twice daily, C_max_=Maximum Serum or Plasma Concentration, MPA=Mycophenolic Acid, MPAG=Mycophenolic Acid Glucuronide, MMF=Mycophenolate Mofetil, NR=Not Reported, PK=Pharmacokinetic, y=Years

One of the adult only studies (n=117) of kidney transplant patients did not find an association between age and MPA predose concentrations.^69^ The other adult study (n=46) found that patients in the MPA AUC_0–12_ >40 μg/mL·h group were slightly but significantly younger than patients in the <40 μg/mL·h group.^18^

Wang et al. compared the pharmacokinetic characteristics of MPA among elderly (defined as over 60 years of age) Chinese renal transplant recipients (n=24) to younger adults (n=24). ^122^ This study found that the MPA AUC was significantly lower in the elderly compared to the younger adult group receiving the same dose of MMF, although the differences in predose, peak concentrations, or peak times were not significant.^122^

Turning to the pediatric only studies, the Bunchman et al.^23^ multicenter, open label, single arm study of MMF oral suspension (n=100) showed no clinically significant differences in MPA and MPAG PK parameters among different age groups. No associations were observed between low MPA and MPAG plasma concentrations and the incidence of acute rejection. Similarly, no associations were found between adverse events and PK parameters. Conversely, an open label, longitudinal evaluation of the PK-pharmacodynamic relationship for total and free MPA in pediatric kidney transplantation (n=54) by Weber et al.,^17^ showed that in the first week post transplant, but not at later, PK sampling periods, low MPA AUC_0–12_ values were associated with young age. The same study showed that both MPA AUC_0–12_ and predose MPA concentrations were significantly associated with the risk of acute rejection in this patient population. By ROC analysis, an AUC_0–12_ of 33.8 mg·h/L in the initial phase post transplant had a diagnostic sensitivity of 75 percent and a diagnostic specificity of 64 percent for discrimination of patients with acute rejections. The respective discrimination threshold for the MPA predose concentrations was 1.2 mg/L, with a sensitivity of 83 percent and a specificity of 64 percent.

In the Weber et al.^112^ pediatric (n=18) versus adult (n=10) kidney transplant study, which was an open label, prospective study to evaluate MPA PK parameters, children displayed concentration-time profiles of total and free MPA after oral administration of 600 mg/m^2^ body surface area twice daily that, in general, were comparable to the profiles of adults receiving 1,000 mg MMF twice daily. This was in the first three weeks post transplant. Mean MPA AUC_0–12_ in pediatric patients one week post transplant was 40 percent higher than in adults, but comparable at three weeks. The AUC_0–12_ values of free MPA at one and three weeks did not differ between children and adults. The authors found higher AUC_0–12_ values for the MPA metabolite MPAG in adult patients compared with children, but this was most likely due to the higher incidence of primary transplant dysfunction in the adults.^112^

The Dipchand et al.^55^ retrospective study involving pediatric heart transplant recipients (n=44) found that increased MPA predose concentrations were significantly associated with older children, thereby implying that higher MMF doses may be required to achieve appropriate MPA concentrations in very young patients.

#### 4b: Gender

The literature search failed to yield studies of direct relevance to this question. Ideally, studies to answer this question would examine the relationship between MPA PK parameters and patient outcomes (e.g. rejection, adverse events) for men versus women. However, three studies^29,^,^52,69^ in kidney transplant patients did examine associations between gender and MPA PK parameters (Table 26). Of these studies, two^29,69^ reported a difference in MPA PK parameters between men and women, while the third^52^ reported no difference. None of the studies examined how the associations might affect patient outcomes.

Table 26 Influence of gender on the utility of monitoring mycophenolic acid in patients who receive a solid organ transplant

Study | Organ | n | Age | % Male | Race | Medications | Health Outcomes Reported | Results
Borrows^69^2005 | Kidney (Renal) | 117 | Mean: 46 +/- 9y | 58.1 | White 55.6% Indo-Asian 23.1 Afro-Carib 17.9% Other 3.4% | Tacrolimus | Infective diarrhea, patient survival, graft survival, biopsy proven acute rejection | Multivariable analysis showed that female gender was associated with higher predose concentrations compared to males (effect size: 1.22; 95% CI: 1.12 to 1.31; p = 0.002)
| | | Range: 37–55y | | | Methylprednisolone
| | | | | | Prednisone
Kuypers^52^2003 | Kidney (Renal) | 100 | Meidan: 51.5y | 59 | NR | Daclizumab (31 patients) | Delayed graft function, mild hepatic dysfunction (abnormal liver function) | MPA PK parameters were not influenced by recipient gender
| | | | | | Tacrolimus
| | | | | | Methylprednisolone
Lu^29^2005 | Kidney (Renal) | 29 | Mean: 40.0 +/- 12.0y | 58.6 | NR | Cyclosporine | Rejection | MPA AUC for females was higher than that of males by 34.3% at the same dose of MMF (p=0.0006)
| | | | | | Prednisone
| | | | | | Tacrolimus

Abbreviatons: AUC=Area-under-the-concentration-time curve, MMF=Mycophenolate Mofetil, MPA=Mycophenolic Acid, NR=Not Reported, PK=Pharmacokinetic, y=Years

The Lu et al.^29^ open label, randomized evaluation of MPA PK parameters in Chinese primary kidney transplant patients (n=29) showed a statistically significant difference in MPA AUC_0–12_ according to gender. MPA AUC for females was higher than that of males by 34.3 percent even though females were receiving the same doses of MMF (p=0.0006). In this study, MPA AUC_0–12_ was lower in the patients who experienced an acute rejection compared to patients who did not (40.93 ± 14.28 μg·h/ml versus 53.88 ± 12.70 μg·h/ml; p=0.038). However, MPA AUC_0–12_ values were not stratified by gender. Similarly, in the Borrows et al.^69^ prospective study of kidney transplant recipients (n=117), multivariable analysis showed that female gender was associated with higher predose concentrations compared to males (effect size: 1.22; 95 percent CI: 1.12 to 1.31; p=0.002). In contrast, a prospective study, by Kuypers et al.,^52^ of 100 de novo, deceased donor, renal transplant patients showed that MPA PK parameters were not influenced by recipient gender. The same study found no significant relationship between acute rejection and MPA AUC_0–12_, C_0_, or C_max_.

#### 4c: Ethnicity

Two studies^20,69^ retrieved in the literature search contained data linking ethnicity and MPA PK parameters (Table 27). Both studies involved kidney transplant patients and suggested there is no association between ethnicity and MPA PK parameters.

Table 27 Influence of ethnicity on the utility of monitoring mycophenolic acid in patients who receive a solid organ transplant

Study | Organ | n | Age | % Male | Race | Medications | Health Outcomes Reported | Results
Borrows^69^ 2005 | Kidney (Renal) | 117 | Mean: 46 +/- 9y | 58.1 | White 55.6% Indo-Asian 23.1 Afro-Carib 17.9% Other 3.4% | Tacrolimus | Infective diarrhea, patient survival, graft survival, biopsy proven acute rejection | No association between ethnicity (White, Indo-Asian, Afro-Caribbean, other) and MPA predose concentrations
| | | Range: 37–55y | | | Methylprednisolone
| | | | | | Prednisone
Shaw^20^ 2000 | Kidney (Renal) | 33 | Range: 47+/-9.7y | 70 | African American: 13 | Neoral Steriods | Impaired Renal Function | No significant differences in MPA AUC values or predose concentrations over the 3-month study period in African Americans compared to Caucasians
| | | | | Caucasian: 20

Abbreviations: AUC=Area-under-the-concentration-time curve, MPA=Mycophenolic Acid, y=Years

The Shaw et al. study^20^ found no significant differences in MPA AUC values over the three month study period in African Americans (n=13) compared to Caucasians (n=20). The MPA predose concentrations were also not statistically significantly different between groups, although the values were generally higher in African Americans. The incidence of acute rejection at three months was 30.8 percent in the African Americans and 15 percent in the Caucasians (p=0.288). The authors suggest that the difference in acute rejection rates may have been due to differences in immune response. Regarding adverse events, the occurrence of diarrhea was not associated with high concentrations of either total or free MPA AUC, predose, or MPAG predose values. The Borrows et al. study^69^ (n=117) showed no association between ethnicity (White, Indo-Asian, Afro-Caribbean, other) and MPA predose concentrations.

#### 4d: Concomitant use of Calcineurin Inhibitors (e.g., Tacrolimus, Cyclosporine)

Studies of direct relevance to this question compared one calcineurin inhibitor (CNI) to another in terms of patient outcomes (e.g., acute rejection or adverse events) related to MPA monitoring. Other studies addressed the effects of CNIs on MPA PK parameters. In our search, we found 12 such studies involving renal transplant patients,^13,^,^29,^,^33,^,^36,^,^38,^,^49,^,^63,^,^64,^,^69,^,^76,^,^77,108^ three involving cardiac transplant patients,^45,^,^58,70^ and two involving liver transplant patients.^40,107^ An additional study compared liver and small bowel transplant recipients to renal transplant recipients (Table 28).^24^

Table 28 Influence of the concomitant use of calcineurin inhibitors on the utility of monitoring mycophenolic acid in patients who receive a solid organ transplant

Study | Organ | n | Age | % Male | Race | Medications | Health Outcomes Reported | Results
Atcheson^13^ 2004 | Kidney (Renal) | 42 | Mean: 44.3 +/- 13.1y | 57 | Caucasian 98% | Cyclosporine n=32 | Rejection, gastrointestinal events, anemia, hematological events thrombocytopenia and leukopenia), infectious events | Patients receiving concomitant tacrolimus had significantly higher MPA predose concentrations compared to patients receiving concomitant cyclosporine
| | | | | | Tacrolimus n=10
| | | | | | Simulect
| | | | | | Diltiazem
| | | | | | Prednisolone
Borrows^69^ 2005 | Kidney (Renal) | 117 | Mean: 46 +/- 9y | 58.1 | White 55.6% | Tacrolimus | Infective diarrhea, patient survival, graft survival, biopsy proven acute rejection | A significant positive association was seen between tacrolimus predose concentration and MPA concentration. There was a significant interaction between this association and time, with larger effect seen early post transplantation
| | | Range: 37–55y | | Indo-Asian 23.1% | Methylprednisolone
| | | | | Afro-Carib 17.9% | Prednisone
| | | | | Other 3.4%
Cantin^58^ 2002 | Heart (Cardiac) | 26 | Mean: 54.4 +/- 14y | 73 | NR | Cyclosporine | Overall rejection | Patients receiving concomitant tacrolimus had significantly higher MPA predose concentrations compared to patients receiving concomitant cyclosporine
| | | Range: | | | Tacrolimus
| | | 22–72y | | | Corticosteroids
Heller^77^ 2007 | Kidney (Renal) | 290 | Mean: 52.5 +/- 13.4y | 62 | White 89.8% | Cyclosporine n=110 | Diarrhea | Tacrolimus/MMF regimen was associated with a higher incidence of diarrhea compared to Cyclosporine/MMF, although MMF dose was similar in the two groups. MPA AUC was lower in the cyclosporine group, but plasma AcMPAG and MPAG were substantially higher with concomitant cyclosporine compared with tacrolimus.
| | | | | Black 1.9% | Tacrolimus n=180
| | | | | Asian 3.2%
| | | | | Other 5.2%
Hesse^45^ 2001 | Heart (Cardiac) | 20 | NR | NR | NR | Tacrolimus | Acute rejection (biopsy score comparison) | Patients receiving concomitant tacrolimus had significantly higher MPA predose concentrations compared to patients receiving concomitant cyclosporine
| | | | | | Prednisone
| | | | | | CsA
Kuypers^36^ 2004 | Kidney (Renal) | 100 | Median 51.5y | 59 | NR | Tacrolimus | Acute rejection | There was no significant correlation between tacrolimus dose, AUC_0–12_, C_0_, C_max_, and systolic, diastolic, and mean arterial pressures at any time point after transplantation.
| | | | | | Methylprednisolone | | Neither for tacrolimus nor for MPA was there a statistically significant difference between recipients with acute rejection and those who remained rejection-free with regard to day 7 AUC_0–12_, MPA, C_0_, C_max_, or dose.
| | | | | | Daclizumab | | In patients who had an acute rejection, the maximum tacrolimus concentration (t_max_) was reached significantly faster than in recipients without rejection.
Lu^29^ 2005 | Kidney (Renal) | 29 | Mean: 40.0 +/- 12.0y | 58.6 | NR | Cyclosporine | Acute rejection | Patients receiving concomitant tacrolimus had significantly higher MPA predose concentrations and MPA AUC compared to patients receiving concomitant cyclosporine
| | | | | | Prednisone
| | | | | | Tacrolimus
Mandla^38^ 2006 | Kidney (Renal) | 78 | Mean: 54y | 73.1 | NR | Tacrolimus | Acute rejection, hypoalbuminemia, delayed graft function | Patients receiving concomitant tacrolimus had significantly higher MPA predose concentrations compared to patients receiving concomitant cyclosporine
| | CsA: 68 | Range: 19–77y | | | Methylprednisolone
| | Tac: 10 | | | | Prednisone
| | | | | | Cyclosporine
Mourad^33^ 2001 | Kidney (Renal) | 51 | Range: 32–68y | 57 | NR | Tacrolimus | Side effects | Patients receiving concomitant tacrolimus had significantly higher MPA predose concentrations and MPA AUC compared to patients receiving concomitant cyclosporine
| | | Median: 49y | | | Corticosteroids
Naito^108^ 2006 | Kidney (Renal) | 25 | Range: 14–60y | 64 | NR | Cyclosporine | Creatinine | No significant difference in MPA predose concentrations between tacrolimus versus cyclosporine treated groups
| | 9 in TAC | | | | Tacrolimus | | No difference in CNI-treated patients compared with patients not receiving concomitant CNIs
| | 3 in CNI,
| | 13 in CsA
Okamoto^49^ 2005 | Kidney (Renal) | 67 | Mean: 38+/-14y | 57 | NR | Cyclosporine n=35 | Acute rejection, adverse events (CMV, Varicella, GI disorder) within 2 weeks after transplantation | MPA AUC _0–9_ and predose concentrations in the cyclosporine group were not different in the AE positive group compared with AE negative group.
| | | | | | Tacrolimus n=32 | Results for Tac treated group vs CsA treated group | MPA AUC _0–9_ and predose concentrations in the tacrolimus group were higher in the AE positive group compared with AE negative group within 2 weeks after transplantation
Pawinski^64^ 2006 | Kidney (Renal) | 33 | Range: 17–62y | 52.9 | NR | Cyclosporine | acute rejection, leucocyte cell count, hemotocrit values, serum creatinine | Patients receiving concomitant tacrolimus had significantly higher MPA predose concentrations and MPA AUC compared to patients receiving concomitant cyclosporine
| | | Mean: 48y | | | Tacrolimus
| | | | | | Prednisone
Ringe^107^ 2001 | Liver | 30 | 51.9 (15–66)y | 70 | NR | Tacrolimus | Acute rejection | Significant correlation between acute rejection and subtherapeutic TAC trough levels, presumably aggravated by poor intestinal drug absorption caused by diarrhea and MMF
| | | | | | | Diarrhea
Sugioka^76^ 2006 | Kidney (Renal) | 83 | Range: | MPA group: 65.1 | NR | Cyclosporine | Leukopenia, Diarrhea | Patients receiving concomitant tacrolimus had significantly higher MPA predose concentrations and MPA AUC compared to patients receiving concomitant cyclosporine
| | Group 1: 63 | MPA group: 7–69y, | PSL group: 55 | | Tacrolimus
| | Group 2: 20 | PSL group: 11–66y | both: 62.7 | | Prednisone
Tredger^40^ 2004 | Liver | 147 adults | Median adults: 50.1y | adults: 53.1 | NR | Cyclosporine | Acute rejection, all gastrointestinal side effects, low total white cell count, leucopenia, neurological episodes, all infections (bacterial, fungal and viral), other adverse events | Median MPA concentrations were lower with tacrolimus than with either cyclosporine or no CNI comedication
| | 63 children | children: 3.5y | children: 49.2 | | Tacrolimus
| | | Range adults: 6.9–71.8y
| | | Range children: 0.3–19.5y
Tsaroucha^24^ 2000 | Kidney (Renal) | Liver: 83 | Mean: | Liver: 70; | NR | Tacrolimus | Rejection, graft survival, patient survival | There was no significant difference between any of the patient groups with respect to MPAG concentrations and tacrolimus blood concentrations.
| Liver | Small bowel: 15 | liver: 41.36 +/- 4.56y; | Small bowel: 40; | | Steroids
| Small bowel | Kidney: 25 | small bowel: 18.69 +/- 3.88y; | Kidney: 52
| | | kidney: 44.25 +/- 2.70y
Weber^63^ 2006 | Kidney (Renal) | 79 | Range: German study: 3.17–16.0y, | German study: 61.1, | NR | German study: | Acute rejection, side effects such as leukopenia and infections | Association between the risk of acute rejection episodes and MPA AUC_0–12_ values in pediatric renal transplant recipients on an immunosuppressive triple drug therapy with MMF, CsA and corticosterioids.
| | condition 1: 54 | suspension trial: 1.0–16.0y | suspension trial: 68.0, both: 63.3 | | Cyclosporine
| | condition 2: 25 | | | | Methylprednisolone
| | | | | | Corticosteroids
| | | | | | Suspension trial:
| | | | | | Cyclosporine
| | | | | | Prednisone
Zakliczynski^70^ 2005 | Heart (Cardiac) | 76 | Mean: 41.9 +/- 16y | 72 | NR | Cyclosporine | Gastrointestinal tract irritation (diarrhea, nausea, vomiting, epigastric pain), leukopoenia, anemia | A significant positive correlation between MPA and CyA concentration was noted in the group of patients with impaired liver function but there was no correlation between MPA and TAC concentration in this group.
| | | | | | Tacrolimus | | No correlation was noted between CyA and MPA concentration, and TAC and MPA concentrations, in the group of patients without impaired liver function.
| | | | | | Prednisone | | The incidence of supratherapeutic MPA concentrations was significantly higher in patients receiving TAC.
| | | | | | Azathioprine

Abbreviations: AE=Adverse events, AUC=Area-under-the-concentration-time curve, CMV=Cytomegalovirus, CNI=Calcineurin Inhibitors, CsA=Cyclosporin A, CyA=Cyclosporine, GI=Gastrointestinal, MPA=Mycophenolic Acid, NR=Not Reported, PSL-Prednisolone, TAC=Tacrolimus, y=Years

Most studies found that the type of concomitant CNI used for maintenance immunosuppression influenced MPA PK parameters. Seven studies of renal transplant recipients (n=29 to 290)^13,^,^29,^,^33,^,^38,^,^64,^,^76,77^ and two studies of cardiac transplant recipients (n=20 to 26)^45,58^ showed that patients receiving concomitant tacrolimus had significantly higher MPA predose concentrations compared to patients receiving concomitant cyclosporine. For example, in Atcheson et al.'s prospective study^13^ of 42 de novo renal transplant patients, patients in the cyclosporine treated group had a mean total MPA predose concentration (for the same dose of MMF) that was approximately half of what patients had in the tacrolimus treated group. Most of these studies also found that not only the predose, but the MPA AUC as well, was significantly higher with co-administration of tacrolimus compared to cyclosporine.^29,^,^33,^,^64,^,^76,77^ In the recent Heller et al. study^77^ performed as a sub-study of a phase IV open, prospective, randomized controlled trial comparing fixed dose versus concentration-controlled MMF regimens for renal transplant recipients, though MPA AUC was higher in patients on concomitant tacrolimus compared with cyclosporine, the plasma AcMPAG and MPAG concentrations were substantially lower in the former group. These data support the assumption that cyclosporine inhibits the biliary excretion of MPAG and AcMPAG, therefore potentially reducing the risk of intestinal injury through enterohepatic recycling of MPA and its metabolites. In this study significantly more patients on tacrolimus suffered from diarrhea compared to cyclosporine (31.1 percent versus 12.7 percent, respectively).

One study, by Naito et al.,^108^ involving 25 Japanese renal transplant recipients showed no significant difference in MPA predose concentrations between tacrolimus versus cyclosporine treated groups. There was also no difference in CNI treated patients compared with patients not receiving concomitant CNIs. The Tredger et al. study^40^ evaluating 95 adult liver transplant patients found median MPA concentrations were lower with tacrolimus than with either cyclosporine or no CNI comedication.^40^ Ringe et al.^107^ found that a two hour dosing interval between MMF and Tacrolimus reduced MPA related diarrhea, resulting in higher Tacrolimus levels.^107^

#### 4e: Concomitant use of Other Medications

Five studies with relevance to this question were retrieved in the literature search (Table 29).^22,^,^50,^,^65,^,^69,78^ The Mudge et al.^65^ open label, RCT in renal transplant recipients (n=40) found no significant effect of oral iron supplements on MMF absorption as measured by MPA AUC measurements. Patients who experienced toxicity showed significantly higher MPA AUC measurements than those who tolerated MMF well. However, there were no significant differences in the occurrence of MMF toxicity between the three groups of no iron versus iron with morning MMF dose versus iron spaced four hours apart from morning MMF dose. There were also no differences between the three groups in the observed frequencies of anemia, leucopenia, thrombocytopenia, infection or gastrointestinal intolerance. Rejection rates were similar between the study groups.

Table 29 Influence of the concomitant use of other medications on the utility of monitoring mycophenolic acid in patients who receive a solid organ transplant

Study | Organ | n | Age | % Male | Race | Medications | Health Outcomes Reported | Results
Borrows^69^ 2005 | Kidney (Renal) | 117 | Mean: 46 +/- 9y | 58.1 | White 55.6% | Tacrolimus | Infective diarrhea, patient survival, graft survival, biopsy proven acute rejection | Treatment with oral augmentin, ciprofloxacin, or metronidazole was associated with a reduction in MPA predose concentrations.
| | | Range: 37–55y | | Indo-Asian 23.1 Afro-Carib 17.9% | Methylprednisolone | | Treatment with intravenous antibiotics (vancomycin, tazocin, and carbopenems) showed no effect.
| | | | | Other 3.4% | Prednisone | | No association between MPA predose concentrations and the use of oral prednisolone, ferrous sulfate, calcium carbonate, or ganciclovir.
Kreis^50^ 2000 | Kidney (Renal) | 78 | SIR: 43.5 +/- 10.9y (22–62); | SIR: 70 | NR | Cyclosporine | Acute rejection rate at 12 months, graft survival, patient survival, renal function | Average daily doses of MMF were significantly lower in the sirolimus group.
| | Condition 1: SIR: 40 | CsA: 42.9 +/- 11.4y (18–60) | CsA: 71 | | Corticosteroids | Compares Sirolimus group to Cyclosporin group | MPA predose concentrations were significantly higher in the sirolimus group.
| | Condition 2: CsA: 38 | | | | Sirolimus
Merkel^22^ 2005 | Kidney (Renal) | 35 | Mean: 44 +/- 13.6y | 68.6 | NR | Cyclosporine | Kidney function (concentration of serum creatinine), rejection, adverse effect (CMV infection) | No effect of concomitant steroids or furosemide on MPA or MPAG predose concentrations.
| | | Range: 13–63y | | | Corticosteroids | | Positive correlation between xipamide (a thiazide diuretic) and MPA predose concentrations.
| | | | | | Prednisone | | A negative correlation between diltiazem and MPA predose concentrations.
Mudge^65^ 2004 | Kidney (Renal) | 45 | Mean: 45.2 +/- 13.2y | 55 | White 98% | Cyclosporine | Toxicity (GI, hematologic, infectious adverse events), biopsy-proven acute rejection (defined according to Banff 1997 criteria) | No significant effect of oral iron supplements on MMF absorption, MMF toxicity, rejection rates, or frequencies of anemia, leucopenia, thrombocytopenia, infection or gastrointestinal intolerance as measured by MPA AUC
| | | | | | Tacrolimus
| | | | | | Prednisone
Wolfe^78^ 1995 | Kidney (Renal) | 12 | Mean: 36 +/- 13y | 100 | NR | Cyclosporine | potential drug interaction between MPA and ganciclovir, creatinine clearance | PK parameters of MPA and MPAG were unchanged by the addition of ganciclovir
| | | Range: 20 to 57y | | | Prednisone
| | | | | | Ganciclovir in 2 arms, one arm alone and 1 arm combined with MMF
| | | | | | Azathioprine

Abbreviations: AUC=Area-under-the-concentration-time curve, CMV=Cytomegalovirus, CNI=Calcineurin Inhibitors, CsA=Cyclosporin A, GI=Gastrointestinal, MMF=Mycophenolate Mofetil, MPA=Mycophenolic Acid, MPAG=Mycophenolic Acid Glucuronide, NR=Not Reported, PK=Pharmacokinetic, PSL=Prednisolone, SIR=Sirolimus, TAC=Tacrolimus, y=Years

A randomized, open label, crossover study, by Wolfe et al.,^78^ involving 12 male kidney transplant recipients evaluated the PK parameters of MPA in patients given 1,500 mg oral MMF alone, MMF and 5 mg/kg intravenous ganciclovir, and ganciclovir alone in separate phases with at least a one week washout period in between. The single dose PK parameters of MPA and its glucuronide metabolite, MPAG, were unchanged by the addition of ganciclovir. Neither the renal elimination nor the metabolism of MPA to MPAG was altered with the addition of ganciclovir, as indicated by the percentage of dose excreted as MPAG and the MPAG:MPA AUC ratio.

The Borrows et al. study^69^ involving 117 renal transplant patients found that treatment with oral augmentin, ciprofloxacin, or metronidazole was associated with a reduction in MPA predose concentrations, but no effect was seen with the use of intravenous antibiotics (vancomycin, tazocin, and carbopenems). The authors explain the lower MPA predose concentration in patients treated with oral antibiotics as being due to a reduction of enterohepatic circulation. An antibiotic induced reduction in enteric organisms possessing glucuronidase leads to decreased recycling of MPAG back to MPA within the bowel and to a consequent reduction in the secondary peak of MPA absorption. The same study found no association between MPA predose concentrations and the use of oral prednisolone, ferrous sulfate, calcium carbonate, or ganciclovir.

Merkel et al.'s^22^ retrospective study of 35 kidney transplant recipients showed no effect of concomitant steroids or furosemide on MPA or MPAG predose concentrations. The same study showed a positive correlation between xipamide (a thiazide diuretic) and MPA predose and a negative correlation between diltiazem and MPA predose.

Kreis et al.'s^50^ randomized trial of kidney transplant patients (n=78) receiving sirolimus or cyclosporine showed that the average daily doses of MMF were significantly lower in the sirolimus group, while MPA predose concentrations were significantly higher in the sirolimus group.

#### 4f: Comorbidity

Studies addressing the effect of renal function on MPA PK parameters provided mixed findings (Table 30). In one study of 46 kidney transplant patients, plasma MPA predose concentrations and MPA AUC_0–12_ were positively and significantly correlated with patients' creatinine clearance values.^18^ A Japanese study involving 25 kidney transplant patients found that MPA and MPAG predose concentrations were influenced by renal function in cyclosporine treated recipients, but not in patients treated with tacrolimus.^108^

Table 30 Influence of comorbidity on the utility of monitoring mycophenolic acid in patients who receive a solid organ transplant

Study | Organ | n | Age | % Male | Race | Medications | Health Outcomes Reported | Results
Behrend^25^ 1997 | Kidney (Renal) | 57 | NR | NR | NR | Cyclosporine | graft function dialysis | No effect of graft function or dialysis on MPA concentrations.
| | | | | | Corticosteroids | adverse events infections | Increase of MPAG with decreasing graft function.
Brunet^66^ 2006 | Liver | 15 | Range: 29 – 66y | 60 | NR | Tacrolimus | Acute rejection | No significant correlation between liver function and MPA concentration and AUC.
| | | | | | Methylprednisolone
| | | | | | Daclizumab
Cattaneo^18^ 2001 | Kidney (Renal) | 46 | Range 19–61y | 63 | NR | Cyclosporine | Creatinine | MPA predose concentrations and MPA AUC_0–12_ were positively and significantly correlated with patients' creatinine clearance values.
| | | | | | Prednisone | Anemia
| | | | | | CSA Neoral | Diarrhea
| | | | | | | Infections
Johnson^123^ 1998 | Kidney (Renal) | 31 | Mean for groups 1–5 | Mean for Groups 1–5 | 6 whites in group 1 & 2, | None | GFR | MPA clearance was not associated with changes in GFR. C_max_ increased as GFR decreased. MPAG clearance correlated with GFR (r^2^=0.90)
| | | 44.5 +/- 15.9y, | 83.3, 66.6, 100, 57.1, 66.6 | 3 white and 3 black in group 3, | | | Clearance of MPA and MPAG were unaffected by hemodialysis, with losses during hemodialysis representing less than 10% of the dose administered
| | | 41.7 +/- 10.3y, | | 6 white and 1 native American in group 4,
| | | 43.8 +/- 10.8y, | | 3 white 1 black and 2 native Americans in group 5
| | | 45.3 +/- 15.0y,
| | | 45.3 +/- 8.5y

Abbreviations: AUC=Area-under-the-concentration-time curve, C_max_=Maximum Serum or Plasma Concentration, GFR=Glomerular Filtration Rate, MPA=Mycophenolic Acid, MPAG=Mycophenolic Acid Glucuronide, NR=Not Reported, y=Years

In a study comparing eight kidney transplant patients with renal insufficiency (defined as creatinine clearance < 20 ml/min) and 15 renal transplant patients with preserved renal function, Kaplan et al.^21^ found that the average free fraction of MPA and the free MPA AUC was approximately double in patients with chronic renal insufficiency compared to patients with normal renal function. MPAG average concentrations in patients with renal insufficiency were significantly higher than patients with preserved renal function. Half of the patients with chronic renal insufficiency developed leucopenia within one month of the kinetic study. This adverse effect occurred in patients with the highest free MPA AUC. None of the patients with preserved renal function developed this complication.^21^ In another study, Shaw et al.^20^ found that impaired renal function lowered the MPA AUC in both African Americans and Caucasians in the early post transplant period. This was attributed to an increased free fraction of MPA in the patients with graft dysfunction as a result of reduced binding of MPA to serum albumin. An open label prospective study evaluating the MPA PK parameters in pediatric kidney transplant patients (n=18) compared with adults (n=10) reported a tight inverse correlation between plasma MPAG AUC_0–12_ values and GFR both in children (r=-0.70, p<0.001) and adults (r=-0.83, p<0.001).^112^

In another study (n=31), Johnson et al.^123^ stratified subjects based on their iohexol clearance and found that MPA clearance was not associated with changes in GFR. C_max_ tended to increase as GFR decreased. MPAG clearance correlated well with GFR (r^2^=0.90). Clearance of MPA and MPAG were unaffected by hemodialysis, with losses during hemodialysis representing less than 10 percent of the dose administered. Morgera et al.^116^ studied the impact of peritoneal dialysis on MPA PK parameters in five patients following renal transplantation. MPA and MPAG AUC decreased during peritoneal dialysis.

In a randomized, placebo controlled trial (n=57 renal transplant patients), the concentrations for MPA were not affected by graft function or dialysis; however, there was an increase of MPAG with decreasing graft function.^25^ In a study of eight kidney transplant patients, renal dysfunction was associated with altered PK parameters of MPA, particularly increased AUC_0–12_ of MPAG, MPA free fraction, and AUC_0–12_ of free MPA. The perturbed PK parameters normalized with improving renal function.^113^ Another prospective study evaluated the impact of peritoneal dialysis on the PK parameters of MPA in five kidney transplant recipients. They found a significant inverse correlation between GFR and MPA-AUC and between GFR and MPAG-AUC.^115^

The effect of liver function on MPA PK parameters is not entirely clear. In the Zakliczynsk et al.^70^ study of 76 cardiac transplant patients, a significant positive correlation was observed between MPA concentrations and cyclosporine in patients with impaired liver function. However, no correlation was noted between MPA predose and cyclosporine in patients without liver dysfunction. Brunet et al.^66^ found no significant correlation when the effect of liver function tests on MPA concentration and AUC was examined in 15 primary cadaveric liver transplant recipients.

In another study, by Naesens et al.,^79^ involving 95 kidney transplant recipients, investigators evaluated the association between single nucleotide polymorphisms (SNP) in the MRP2 gene and MPA PK parameters. In patients not carrying the MRP2 C-24T SNP gene, the investigators found a marked difference in MPA exposure between patients with and without liver dysfunction. Patients with mild liver disease had significantly lower MPA dose corrected predose concentrations, a lower dose corrected MPA AUC_0–12_, and higher calculated MPA clearance.

### Question 4. Summary

Based on the current evidence available, some of the six components of this question appear to influence MPA PK parameters. However, none of the included studies investigated whether PK parameter levels, stratified by each component, were associated with outcomes such as rejection or adverse events. Regarding age, the evidence was equivocal. In pediatric populations, younger children were found to require a higher MMF dose to achieve a specified MPA concentration. Regarding gender, the evidence appears to indicate that PK parameters are higher for females versus males. Race and ethnicity do not appear to influence MPA PK parameters. Calcineurin inhibitors are co-administered frequently with MMF and the bulk of the evidence found that exposure to MPA is higher in patients receiving tacrolimus compared to cyclosporine, with lower doses of MMF required in combination with tacrolimus to achieve adequate MPA exposure. Total MPA PK parameters were generally higher in persons with renal insufficiency, although one study found lowered MPA AUC in the early post transplant period.

### Question 5. What is the Short- and Long-Term Cost-Effectiveness of Avoiding Acute Rejection due to MPA Monitoring?

Findings from the abstracted studies. None of the abstracted studies contained any data on the cost-effectiveness associated with MPA monitoring. There is no evidence in the literature on the cost-effectiveness of MPA monitoring.

## Quality Assessment of Abstracted Studies

Twelve of the 89 abstracted studies were RCTs^10^–^12,^,^25,^,^28,^,^29,^,^34,^,^50,^,^51,^,^65,^,^68,78^ and the remainder were observational studies (primarily case series). The quality of the RCTs was fair to good. Eleven studies contained baseline comparisons of treatment groups (three had minor differences on one or two variables), 11 used ITT analyses, eight clearly reported the methods used to measure MPA, and 10 had clear definitions of outcomes related to measuring MPA. Conversely, reporting of some essential features of trial design was lacking. The method of randomization was described in five studies and the means of treatment allocation was described in two studies. The authors of three studies reported that subjects and persons assigned to measure MPA were blinded; four studies contained reports of blinding amongst outcome assessors. One of the RCTs^10^ contained reports of differential losses to followup. Although it appears from the published reports that there were no losses to followup in the other reports, the authors did not specifically state whether any such losses occurred.

Compared to the RCTs, the 77 observational studies suffered from numerous reporting problems. Virtually all of the studies lacked reports of blinding among subjects (n=73), persons measuring MPA (n=74), and outcomes assessors (n=75). Differential losses to followup were not reported in 61 studies. The authors of only 29 studies made an attempt to control for confounding. Some aspects of reporting were good, though, as the authors of most of the observational studies described the methods used to measure MPA (n=68) and clearly defined their outcomes (n=69).

The most troublesome aspects of study quality were the failure to report blinding in a majority of the studies and the failure to control for confounding in most of the observational studies. For blinding, it is often debatable whether the issue reflects poor study quality or poor reporting. For confounding, the very nature of observational studies suggests that the influence of ‘third party’ variables should be considered in the design or analysis stage. To do otherwise is a serious omission.