# Methods

## Analytic Framework

An analytic framework is a schematic representation of the strategy for organizing topics for review and guiding literature searches. Figure 2 illustrates the inter relationships between the key questions for this evidence report. The figure begins with the use of CellCept^®^ or Myfortic^®^ in solid organ transplant recipients, progresses to monitoring MPA (mycophenolic acid) concentrations in serum or plasma, and concludes with an outcome (e.g., rejection or adverse events). Throughout the entire diagram, each box is suggestive of an area where resources are consumed. The cost of these resources may be computed using standard health economics methods and compared to an outcome (e.g., life years gained, quality adjusted life years gained) to obtain incremental cost effectiveness ratios.^100^

Figure 2. Analytical Framework

Within the ‘monitoring’ subsection of the framework, the issues to consider are the form and method of MPA monitoring. In our analysis of form, we also include the type of MPA (total [bound and free], free) and the means for measuring each type in serum or plasma, namely assays such as HPLC (High-Performance Liquid Chromatography), HPLC-MS (High-Performance Liquid Chromatography-Mass Spectrometry), or EMIT (Enzyme-Multiplied Immunoassay Technique). In our analysis of form, we also include variations in albumin (to which MPA binds strongly), concentrations of MPA metabolites, and pharmacogenetics. Methods of monitoring include total AUC_0–12_ (area under the curve) and limited sampling strategies such as two hour (2h) post dose concentrations and predose concentrations.

Several factors are hypothesized to affect the utility of MPA monitoring, including age, gender, ethnicity, use of calcineurin inhibitors or concomitant medications, and comorbidity. This is because these factors may influence the disposition of MPA (i.e., adsorption, distribution, metabolism, or excretion).

## Topic Assessment and Refinement

### Research Team

The McMaster University Evidence-based Practice Center (MU-EPC) assembled a multidisciplinary research team with expertise in epidemiology and systematic reviews (M. Oremus, Ph.D.; P. Raina, Ph.D.), toxicology (J. Zeidler, Ph.D.), clinical chemistry (C. Balion, Ph.D.), pediatric nephrology (M. Matsuda-Abedini, M.D.), and pharmacy (M. Ensom, Pharm.D.). The team was tasked with planning an approach to completing this evidence report in a thorough, timely, and efficient manner. The team had regular meetings in the initial stages of the project to reach consensus on key methodological issues. The team was also responsible for supervising the literature search, screening, and data abstraction. The team synthesized the literature and wrote the discussion.

The research team held a ‘kick-off’ teleconference with representatives from the partner organization (American Association of Clinical Chemistry), the Agency for Healthcare Research and Quality (AHRQ), and MU-EPC staff at the start of the project to define the magnitude of the topic and refine and clarify the preliminary key questions. A Technical Expert Panel (TEP), composed of internationally recognized experts in MPA, was assembled to provide high level content expertise on MPA monitoring. Members of the TEP were requested to participate in teleconferences on an as needed basis throughout all phases of the project.

### Technical Expert Panel Teleconference Calls

The first TEP teleconference call took place on February 8, 2007. Technical experts included Dr. Klemens Budde (Managing Senior Physician, University Clinic Charité), Dr. Guido Filler (Chair/Chief, Department of Pediatrics, Children's Hospital of Western Ontario), Dr. Atholl Johnston (Professor of Clinical Pharmacology, Barts and the London, Queen Mary's School of Medicine and Dentistry), and Dr. Leslie M. Shaw (Professor of Pathology and Laboratory Medicine, Hospital of the University of Pennsylvania) (see Appendix E^*^ for a list of TEP members). A second TEP teleconference took place on April 18, 2007 (Drs. Budde, Filler, Johnston, and Shaw present). Several topics were discussed during both calls, including the definition and scope of the key questions, search strategies, inclusion and exclusion criteria, and the composition of the screening and data abstraction forms.

* Appendixes and Evidence Tables for this report are provided electronically at http://www.ahrq.gov/clinic/tp/mpaorgtp.htm

## General Methods

### Key Questions

The original set of key questions for this evidence report was revised by the MU-EPC research team and discussed during the TEP teleconferences. Additional discussants at the teleconferences included representatives from the partner organization and the AHRQ's Task Order Officer (TOO).

The revised key questions are:

1 What is the evidence that monitoring mycophenolic acid in patients who receive a solid organ transplant results in a lower incidence of transplant rejections and adverse events compared to patients who are not monitored?
2 Does the incidence differ by any of the following?
  a) MPA dose and dose frequency;
  b) Type of MPA (mycophenolate mofetil [CellCept^®^], enteric-coated mycophenolate sodium [Myfortic^®^]).
3 a) Does the incidence differ by any of the following?
    ia) Total versus free MPA
    ib) Albumin versus MPA
    iia) MPAG, AcMPAG versus MPA
    iib) Genetic basis of differences in MPA pharmacokinetic parameters
    iii) Assay method (HPLC, EMIT, HPLC-MS, other)
  b) Does the incidence differ by analytical method of MPA monitoring?
    i Full AUC
    ii Limited sampling strategies
      a Predose concentrations
      b 2h post dose concentrations
      c Other
4 Does the evidence for monitoring MPA differ by any of the following?
  a) Age
  b) Gender
  c) Ethnicity
  d) Concomitant use of calcineurin inhibitors (e.g., tacrolimus, cyclosporine)
  e) Concomitant use of other medications
  f) Comorbidity
5 What is the short- and long-term cost-effectiveness of avoiding acute rejection due to MPA monitoring?

### Literature Search Strategy

We conducted a comprehensive search of the literature to capture all relevant, published studies on the topic of therapeutic drug monitoring (TDM) for MPA. The following electronic databases were searched:

1 MEDLINE^®^ (1966- October 22, 2007);
2 BIOSIS^®^ Previews (1976- October 22, 2007);
3 EMBASE^®^ (1980- October 22, 2007);
4 Cochrane Database of Systematic Reviews^®^ (1995- October 22, 2007);
5 Cochrane Central Register of Controlled Trials^®^ (1995- October 22, 2007).

Appendix A^*^ contains a detailed description of the database search strategies.

To supplement the database search, we examined the reference lists of several recently published review articles^3^–^6^ and consulted with the TEP to identify additional published studies.

Inclusion/exclusion criteria. We included studies published in the English language, provided they were randomized controlled trials (RCTs), observational studies with comparison groups (e.g., cohort, case control), or case series (a retrospective or prospective study with a single group of subjects [no comparison group] enrolled according to predefined criteria). Case reports, narrative and systematic reviews, editorials, comments, letters, opinion pieces, abstracts, conference proceedings, and animal experiments were excluded from the report. We included studies of pediatric and adult patients who received allograft solid organ transplants from live or deceased donors, provided that any form of MPA was measured in serum or plasma. At least one measure, at one point in time, had to be made using any method of measurement (e.g., AUC). We excluded studies that did not link the measures of MPA in blood to a health outcome. Examples of health outcomes included transplant rejection, graft survival, overall patient survival, or mortality. Certain biomarkers (e.g., serum creatinine, glomular filtration rate [GFR]) and all adverse events were also considered health outcomes.

### Data Collection and Reliability of Study Selection

A team of trained raters, composed of research assistants, MU-EPC staff, and members of the research team, applied the inclusion and exclusion criteria to the citations that were identified in the literature search (see Appendix B). A guide and standardized forms were developed to govern the screening process. The forms were created and stored online using Systematic Review Software v4.0 (SRS; TrialStat Corp., Ottawa, Ontario, Canada).

The screening process was divided into two levels: title and abstract, and full text. For title and abstract screening, two independent raters evaluated the citations that were obtained from the literature search. Citations that met the inclusion criteria or for which there was insufficient information to determine whether or not they did, were retrieved for further assessment. Once retrieved, the entire study publication (full text) was screened to determine if the inclusion criteria were met. At this stage, the raters assigned the included studies to categories based on the key question or questions to which the studies applied. Inclusion of studies required agreement from both raters. Discrepancies were resolved by consensus. If consensus could not be reached, then a third party arbitrator reviewed the study in question and made a final decision. The arbitrator was an epidemiology trained member of the MU-EPC staff who was not otherwise involved in the screening process.

Studies that passed the full text screening phase proceeded to full data abstraction. Data were abstracted by MU-EPC staff (including two trained physicians). Members of the research team who were responsible for synthesizing data for the key questions reviewed the abstractions to confirm the accuracy of the work.

### Quality Assessment of Included Studies

The methodological quality of included studies was assessed using ‘core’ criteria enumerated in the draft Evidence-based Practice Center Methods Manual (under preparation by the AHRQ). These core criteria represent the most important elements by which to judge study quality.^101,102^ The criteria were formulated into questions, which are shown in Appendix B^*^. Two reviewers independently assessed study quality and resolved discrepancies by consensus.

For controlled trials, we examined the following topics: method of randomization, method of allocation concealment, baseline comparison of groups, differences between groups at baseline, availability of intent to treat analysis, description of methods used to measure MPA, definition of the outcomes related to monitoring MPA, blinding of subjects, persons measuring MPA, persons assessing outcomes and the presence of a differential loss to followup between groups.

For observational studies, we examined the following topics: sample size for primary and secondary outcomes, selection method of subjects, baseline comparison of groups, differences between groups at baseline, description of the methods used to measure MPA, definition of outcomes related to monitoring MPA, blinding of subjects, persons measuring MPA, persons assessing outcomes, presence of a differential loss to followup between groups and whether the authors controlled for confounding.

### Summary of Findings: Descriptive and Analytic Approaches

A qualitative descriptive approach was used to summarize study characteristics and outcomes. Multiple reports on the same study cohort were grouped together and treated as a single study with the most current data reported for presentation of summary results.

Descriptive approaches were used to summarize the characteristics of included studies and answer the key questions. The research team judged that a meta-analysis was not feasible because the included studies contained far too much clinical and methodological heterogeneity. Instead, data were collected during the abstraction on the characteristics of study participants, treatment regimen, form of MPA, method of measuring MPA, measurement time points, and outcomes. The quality of this information was judged and the findings were summarized in both text and tables. This evidence report provides a greater understanding of TDM for MPA, identifies gaps in existing research, and suggests future research.

## Peer Review Process

The partner organization, TOO, research team, and members of the TEP identified potential peer reviewers. The MU-EPC compiled a list of these reviewers, all of whom were approved by the AHRQ prior to the circulation of the draft report. The reviewers were asked to review the report and provide feedback on clinical and methodological content, as well as on the readability and presentation of information. Their comments and suggestions were incorporated where possible.