# Introduction

## Mycophenolic Acid

Mycophenolic acid (MPA) is an immunosuppressant drug used to prevent rejection of solid organ transplants. MPA reversibly inhibits inosine monophosphate dehydrogenase (IMPDH), the rate limiting step in the biosynthesis of guanine nucleotides. The drug is marketed as the ester prodrug mycophenolate mofetil (CellCept^®^) for kidney, liver, and heart transplants or enteric-coated mycophenolate sodium (Myfortic^®^) (ECMPS) for kidney transplants. The chemical formula is C_17_H_201_O_6_ and the structural formula is shown in Figure 1. The molecular mass is 320.34 g.mol^-1^.

Figure 1. Structural Formula for Mycophenolate Acid

Mycophenolate mofetil comes in capsule (250 mg), tablet (500 mg), powder (200 mg/mL constituted), and intravenous (500 mg) formulations. ECMPS comes in delayed release tablets (180 mg or 360 mg). Recommended dosage regimens for adults on mycophenolate mofetil are 1 g orally twice daily for kidney transplant recipients, 1 g twice daily intravenously or 1.5 g twice daily orally for liver transplant recipients, and 1.5 g intravenously or orally for cardiac transplant recipients. Recommended dosages for adult kidney transplant recipients on ECMPS are 720 mg twice daily. In pediatric patients, recommended dosages for MMF are 600 mg/m^2^ administered orally twice daily (maximum 2 g or 10 mL daily), while children with a body surface area of 1.25 to 1.5 m^2^ are recommended to get 750 mg twice daily. Children with a body surface area greater than 1.5 m^2^ are recommended to receive 1g twice daily.^80^ Although Tacrolimus has replaced Cyclosporin A as calcineurin inhibitor comedication to a large degree, MPA was originally approved by the U.S. Food and Drug Administration only for combination with Cyclosporin. The recommended doses refer to this combination.

The pro-drug Mycophenolate mofetil is rapidly hydrolyzed to MPA by esterases in the gut, blood, liver, and kidney. ECMPS does not get hydrolyzed; it is essentially MPA in salt form. Oral bioavailability of MPA is between 81 and 94 percent after ingestion of mycophenolate mofetil and 72 percent after ingestion of ECMPS. Differences in bioavailability may be due to the fact that studies of mycophenolate mofetil were conducted on healthy volunteers while studies of ECMPS (e.g., Arns et al.^81^) were conducted on kidney transplant patients. MPA is metabolized in the liver, gastrointestinal tract, and kidney. The major metabolite, 7-O-MPA-glucuronide (MPAG), is inactive, and occurs in 20 to 100-fold higher concentrations than MPA.^80^ The minor acyl glucuronide metabolite AcMPAG is immunosuppressive and proinflammatory. Enterohepatic recirculation of MPA involves excretion of MPAG into bile followed by deconjugation to MPA in the gut and reabsorption into the circulation. This effect accounts for 10 to 60 percent of MPA exposure and may lead to a second peak in the MPA concentration 6 to 12 hours after dosing. Readers interested in further information on the pharmacodynamics and pharmacokinetics of MPA are referred to reviews by Staatz and Tett^80^ and Bullingham et al.^82^

## Solid Organ Transplant

Solid organs include the kidneys, liver, heart, lungs, pancreas, and intestines. In 2005, there were 25,737 solid organ transplants in the United States alone.^83^ These transplants are used to treat end stage organ failure. One year graft survival rates range from 82.0 to 95.0 percent, due in large part to refined surgical techniques and the development of effective immunosuppressant drugs. The success of solid organ transplants has led to a situation where demand for organs far outstrips supply. In mid-2005, over 90,000 Americans were on waiting lists for solid organ transplants.^84^

## Mycophenolic Acid: Use in Solid Organ Transplants

Mycophenolate mofetil. The use of mycophenolate mofetil in solid organ transplants is based on the results of five seminal, randomized controlled trials of kidney,^85^–^87^ liver,^88^ and cardiac transplant recipients.^89^ In four trials, patients were randomized to receive mycophenolate mofetil or azathioprine in combination with cyclosporine and corticosteroids; one kidney trial^85^ involved mycophenolate mofetil and a placebo comparison. The average duration of the trials was six to 12 months post transplant. Some data are available for 36 months post transplant.^90^–^92^

For the three kidney trials,^85^–^87^ a total of 1,493 patients were randomized to treatment. Results showed benefits for 2 and 3 g daily doses of mycophenolate mofetil (MMF2, MMF3) at six months; however, benefits diminished or disappeared at 12 months and beyond. The percentage of patients with biopsy proven rejection in the placebo comparison trial^85^ at six months was 17.0 percent in the MMF2 group, 13.8 percent in the MMF3 group, and 46.4 percent in the placebo group (p≤0.001). At 36 months, the difference in graft loss rates for intent-to-treat comparisons versus placebo were 7.3 percent (95 percent confidence interval [CI]: 1.1 to 14.2; p<0.05) for MMF2 and 3.2 percent (95 percent CI: -3.8 to 10.1; p>0.05) for MMF3.^90^ In the two kidney trials where mycophenolate mofetil was compared to azathioprine, the primary outcome at six months was ‘treatment failure’ (any one of the following: biopsy proven rejection, graft loss, death, withdrawal for any reason). The percentage of patients with treatment failure in one study,^86^ based in the United States, was 31.1 percent in the MMF2 group, 31.3 percent in the MMF3 group, and 47.6 percent in the azathioprine group (p=0.021). Percentages in the other study,^87^ a multinational effort, were 38.2 percent for MMF2, 34.8 percent for MMF3, and 50.0 percent for azathioprine (p<0.03). The percentages of patients suffering graft loss or death at 12 months in the multinational study were 11.7 percent in the MMF2 group, 11.0 percent in the MMF3 group, and 13.6 percent in the azathioprine group (p>0.05). The investigators in the multinational trial reported intent to treat results at 36 months: graft and survival for patients receiving MMF2 was 81.9 percent, MMF3 was 84.8 percent, and azathioprine was 80.2 percent (p>0.05).^91^

In the liver study,^88^ 565 patients were randomized to treatment and results favored mycophenolate mofetil after six months of followup. However, there was no difference between mycophenolate mofetil and azathioprine after one year of followup. Percentages of acute rejections and graft losses at six months were 38.5 percent in the mycophenolate mofetil group and 47.7 percent in the azathioprine group (p<0.03). At 12 months, percentages were 31.0 percent and 40.0 percent respectively (p<0.06). Graft survival at 12 months was 85.3 percent the mycophenolate mofetil group and 85.4 percent in the azathioprine group (p>0.05).

In the heart study,^89^ primary results were reported for 578 ‘treated’ patients who received the study medication to which they were randomized. A further 72 randomized patients withdrew from the study before initiation of treatment. At six months, 65.7 percent of mycophenolate mofetil and 73.7 percent of azathioprine patients required treatment for rejection (p=0.026). Mortality at 12 months was 6.2 percent in the mycophenolate mofetil group and 11.4 percent in the azathioprine group (p=0.031). At 36 months, 11.8 percent of the mycophenolate mofetil group and 18.3 percent of the azathioprine group died or received another transplant (p<0.01).^92^

Enteric-coated mycophenolate sodium. ECMPS was shown to be therapeutically equivalent to mycophenolate mofetil in two trials that were initially reported in a single publication.^1^ Trial 1 contained 424 de novo kidney transplant patients and trial 2 contained 324 stable maintenance kidney transplant patients who were alive at six months post transplant. In trial 1, patients were randomized to 720 mg of oral ECMPS and placebo twice daily, or to 1,000 mg of oral mycophenolate mofetil and placebo twice daily. Placebos were disguised to look like the active drug being given in the opposing treatment arm. The primary outcome was ‘treatment failure’ (any one of the following: biopsy proven acute rejection, graft loss, death, or loss to followup within six months). After six months, 25.8 percent of patients in the ECMPS group and 26.2 percent in the mycophenolate mofetil group experienced a treatment failure (p>0.05). Failure results^93^ at 12 months were 26.3 percent (ECMPS) and 28.1 percent (MMF) (p>0.05). Trial 2 patients were randomized to 720 mg of oral ECMPS daily or to 1,000 mg of oral MMF daily. The primary outcome was the incidence of gastrointestinal adverse events or neutropenia (less than 1,500 cells per mm^3^). At three months, there was no difference in incidence of gastrointestinal adverse events (26 percent in the ECMPS group; 21 percent in the MMF group [p>0.05]). Nor was there a difference at six months (29 percent ECMPS; 28 percent MMF [p>0.05]). The authors reported the incidence of neutropenia after three months to be lower in patients receiving ECMPS (0.6 percent) versus patients receiving MMF (3.1 percent [p>0.05]). Neutropenia results were unchanged after 12 months of followup.^94^ Concomitant therapies in both trials included cyclosporine with or without corticosteroids.

ECMPS and MMF were also compared in a single blind trial of 154 de novo heart transplant patients.^95^ Results showed therapeutic equivalence between drugs. Patients were randomized to 1,080 mg ECMPS twice daily or to 1,500 mg MMF twice daily. ‘Treatment failure’ (biopsy proven and treated acute rejection, graft loss, or death) was the outcome. The percentage of patients having the outcome did not differ (p>0.05) between groups at six or 12 months of followup: 52.6 percent versus 57.9 percent at six months and 57.7 percent versus 60.5 percent at 12 months.

Adverse events. Common adverse events of MPA include gastrointestinal upset (nausea, vomiting, mild diarrhea), headache, mild weakness, dizziness or tremor, insomnia, and swelling of the lower legs or feet. There is also an increased risk of lymphoma or other cancers.^96^

In clinical trials, patients taking mycophenolate mofetil had more abdominal pain, diarrhea, esophagitis, anorexia, gastrointestinal bleeding, leucopenia, anemia, and opportunistic infections (e.g., cytomegalovirus [CMV], herpes simplex or zoster) than patients taking placebo or azathioprine. Patients taking 3 g MMF daily generally had more adverse events than patients taking 2 g MMF daily. There were no differences in the incidence of cancers between any of the treatment groups.^85^–^89^ In trials where mycophenolate mofetil was compared to ECMPS,^1,^,^93,94^ adverse events were generally higher in the MMF group, although the differences were not statistically significant at the 5 percent level. The incidence of gastrointestinal adverse events was higher in the ECMPS group (29.6 percent versus 24.5 percent),^94^ although the difference was also not statistically significant. The incidence of cancer did not differ between treatments.

## Therapeutic Drug Monitoring of Mycophenolic Acid

Therapeutic drug monitoring (TDM) is the measurement and subsequent interpretation of drug concentrations in biological fluid. Drugs exhibiting the following characteristics may warrant TDM: a good relationship between concentration and pharmacological response; wide interpatient variation in absorption, distribution, metabolism, or excretion; a narrow therapeutic range; and a pharmacological response that is not readily assessable. TDM may be useful for monitoring adherence, identifying drug interactions, and tailoring doses to specific patients.^97^

TDM has become central to the use of immunosuppressants. The aim is to improve control over acute rejection and boost the probability of long term patient and graft survival.^98^ TDM of MPA is based on observed associations between total MPA area under the concentration-time curve (AUC_0–12 h_) and acute rejection in adult and pediatric patients.^11,^,^17,^,^42,99^ However, this evidence is viewed by some as equivocal.^2,3^

Additionally, there are numerous challenges that must be addressed as a prerequisite for TDM of MPA. Most notable is the impracticality of repeated 12 hour measures of AUC in standard practice settings. There have been suggestions of methods to overcome the impracticality of total AUC (e.g., use of limited sampling strategies^4^ or Bayesian estimation^2^), but none of these possibilities has been thoroughly investigated to date.

Other challenges include the difficulty of using existing, routine assays to quantitate free MPA, which is thought to be the prime driver of MPA's immunosuppressive effect, as well as the need to establish and validate effective therapeutic ranges for TDM.^4^ Some researchers^3^ do not believe that free MPA has much of a role in TDM because its correlation with clinical outcomes is not improved over the correlation between total MPA and clinical outcomes. Recently Roche has introduced an IMPDH based assay for free and total MPA. A CEDIA assay is now available from Microgenics.

Improved prophylaxis with multiple drugs has lowered the rejection risk. This makes additional improvements based on dosing of one drug and definition of a lower limit of the therapeutic range challenging.

Further issues in TDM of MPA include wide intra patient variability in MPA plasma concentration-time profiles, non-linear pharmacokinetics, increase of MPA exposure with time early after kidney transplantation, no established frequency and duration of monitoring, uncertainty about the extent to which baseline IMPDH may contribute to pharmacodynamic differences in persons receiving MPA, problematic bioavailability in renally impaired patients, and no agreement on a pharmacokinetic (PK) parameter that would best associate with adverse events.^4^ Some^6^ believe the occurrence of gastrointestinal adverse events may be associated with dose rather than a pharmacokinetic variable. Adverse events are relatively rare, not specific to MPA, and thus difficult to assess objectively. An upper limit of a therapeutic range is therefore difficult to determine.

## Scope and Purpose of the Evidence Report

This evidence report was designed and conducted to address the following key questions:

1 What is the evidence that monitoring mycophenolic acid in patients who receive a solid organ transplant results in a lower incidence of transplant rejections and adverse events compared to patients who are not monitored?
2 Does the incidence differ by any of the following?
  a) MPA dose and dose frequency;
  b) Type of MPA (mycophenolate mofetil [CellCept^®^], enteric-coated mycophenolate sodium [Myfortic^®^]).
3 a) Does the incidence differ by any of the following?
    ia Total versus free MPA
    ib Albumin versus MPA
    iia) MPAG, AcMPAG versus MPA
    iib) Genetic basis of differences in MPA pharmacokinetic parameters
    iii) Assay method (EMIT, HPLC, HPLC-MS, other)
  b) Does the incidence differ by analytical method of MPA monitoring?
    i Full AUC (area under the curve)
    ii Limited sampling strategies
      a Predose concentrations
      b 2h post dose concentrations
      c Other
4 Does the evidence for monitoring MPA differ by any of the following?
  a) Age
  b) Gender
  c) Ethnicity
  d) Concomitant use of calcineurin inhibitors (e.g., tacrolimus, cyclosporine)
  e) Concomitant use of other medications
  f) Comorbidity
5 What is the short and long-term cost-effectiveness of avoiding acute rejection due to MPA monitoring?

Addressing these questions will help to gauge the strength of the evidence for TDM of MPA in solid organ transplants. As well, the exercise will identify gaps in the research and provide suggestions for future research.