# Appendix E. Technical Expert Panel and Peer Reviewers

## Members of the Technical Expert Panel (TEP)

- Prof. Dr. Klemens Budde
- Med. Klinik m.S. Nephrologie
- Charité Universitätsmedizin Berlin
- Germany

- Dr. Guido Filler
- Chair/Chief, Department of Paediatrics
- Children's Hospital of Western Ontario
- University of Western Ontario
- London, ON, Canada

- Dr. Maria Shipkova
- Zentralinstitut für Klinische Chemie
- und Laboratoriumsmedizin
- Klinikum Stuttgart
- Katharinenhospital
- Stuttgart, Germany

- Dr. Leslie M. Shaw
- Professor and Director
- Clinical Toxicology Laboratory
- Director
- Xenobiotic Toxicokinetics Research Laboratory
- University of Pennsylvania Medical Center
- Philadelphia, PA, USA

- Dr. Atholl Johnston
- Professor of Clinical Pharmacology
- Barts and The London Charterhouse Square
- London, UK

## Peer Reviewers of the Report

- Dr. Susan Maynard
- Department of Chemistry, Toxicology, and Blood Gases
- Carolinas Medical Center
- Charlotte, North Carolina, USA

- Dr. Robert H. Christenson
- Professor of Pathology & Medical and Research Technology
- Maryland School of Medicine
- Baltimore, MD, USA

- Prof. Dr. Klemens Budde
- Med. Klinik m.S. Nephrologie
- Charité Universitätsmedizin Berlin
- Germany

- Dr. Maria Shipkova
- Zentralinstitut für Klinische Chemie
- und Laboratoriumsmedizin
- Klinikum Stuttgart
- Katharinenhospital
- Stuttgart, Germany

- Dr. Michael Oellrich
- Director Department of Clinical Chemistry
- Georg-August Universitat
- Gottingen, Germany

- Dr. Darin Treleaven
- Department of Nephrology
- St. Joseph's Healthcare
- Hamilton, ON, Canada

- Dr. Teun van Gelder
- Renal Transplant Unit and Clinical Pharmacology Unit
- Erasmus Medical Center
- Rotterdam, The Netherlands

- Dr. David W Holt
- Clinical Toxicology Department of Cardiological Sciences
- St. George's Hospital
- London, ON, Canada