# Appendix D. List of Excluded Studies

## References

CellCept shown to improve 3-year graft survival in renal transplantation. Dialysis & Transplantation 1997;26(8):523 Excluded because not a full report of an included study type
Aigrain EJ, Shaghaghi EK, Baudouin V, et al. Pharmacokinetics of mycophenolate mofetil in eight pediatric renal transplant patients. Transplant Proc. 2000;32(2):388-90. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 10715449].
Akhlaghi F, Patel CG, Zuniga XP, et al. Pharmacokinetics of mycophenolic acid and metabolites in diabetic kidney transplant recipients. Ther Drug Monit. 2006;28(1):95-101. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16418701].
Akoglu B, Wondra K, Caspary WF, et al. Determinants of fasting total serum homocysteine levels in liver transplant recipients. Exp Clin Transplant. 2006;4(1):462-6. Excluded because MPA not measured in blood. [pmid: 16827644].
Al Aly Z, Sachdeva A, Philoctete Ashley JM, et al. Preliminary experience with mycophenolate mofetil for preservation of renal function in cardiac transplant patients with documented cyclosporine nephrotoxicity. Nephrology. 2006;11(2):151-5. Excluded because not a full report of an included study type. [pmid: 16669979].
Al Khoury S, Shah N, Afzali B, et al. Post-transplantation anaemia in adult and paediatric renal allograft recipients - Guy's Hospital experience. Nephrol Dial Transplant. 2006;21(7):1974-80. Excluded because MPA not measured in blood. [pmid: 16595586].
Anil Kumar MS, Moritz MJ, Saaed MI, et al. Avoidance of chronic steroid therapy in African American kidney transplant recipients monitored by surveillance biopsy: 1-year results. Am J Transplant. 2005;5(8):1976-85. Excluded because MPA not measured in blood. [pmid: 15996248].
Annesley TM, Clayton LT. Quantification of mycophenolic acid and glucuronide metabolite in human serum by HPLC-tandem mass spectrometry. Clin Chem. 2005;51(5):872-7. Excluded because not a full report of an included study type. [pmid: 15746301].
Arbogast H, Huckelheim H, Schneeberger H, et al. A calcineurin antagonist-free induction/maintenance strategy for immunosuppression in elderly recipients of renal allografts from elderly cadaver donors: long-term results from a prospective single centre trial. Clin Transplant. 2005;19(3):309-15. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15877790].
Armstrong VW, Tenderich G, Shipkova M, et al. Pharmacokinetics and bioavailability of mycophenolic acid after intravenous administration and oral administration of mycophenolate mofetil to heart transplant recipients. Ther Drug Monit. 2005;27(3):315-21. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15905802].
Arns W, Breuer S, Choudhury S, et al. Enteric-coated mycophenolate sodium delivers bioequivalent MPA exposure compared with mycophenolate mofetil. Clin Transplant. 2005;19(2):199-206. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15740555].
Arns W, Gies M, Choi L, et al. Absorption characteristics of EC-MPS - An enteric-coated formulation of mycophenolic sodium. Int J Clin Pharmacol Ther. 2006;44(8):375-85. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16961168].
Atcheson BA, Taylor PJ, Kirkpatrick CM, et al. Free mycophenolic acid should be monitored in renal transplant recipients with hypoalbuminemia. Ther Drug Monit. 2004;26(3):284-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15167629].
Au WY, Lie AK, Cheng VCC, et al. Successful Lung Transplantation for Post-BMT Bronchiolitis Obliterans and Lipoid Pneumonia Associated with Atypical Mycobacterium and Aspergillosis Infection. J Heart Lung Transplant. 2007;26(8):870-2. Excluded because not a full report of an included study type. [pmid: 17692797].
Augustine JJ, Knauss TC, Schulak JA, et al. Comparative effects of sirolimus and mycophenolate mofetil on erythropoiesis in kidney transplant patients. Am J Transplant. 2004;4(12):2001-6. Excluded because MPA not measured in blood. [pmid: 15575902].
Aumente R, Arizon Del Prado JM, Lopez Malo De Molina MD, et al. Clinical pharmacokinetics of tacrolimus in heart transplantation: new strategies of monitoring. Transplant Proc. 2003;35(5):1988-91. Excluded because MPA not measured in blood. [pmid: 12962871].
Aw MM, Brown NW, Itsuka T, et al. Mycophenolic acid pharmacokinetics in pediatric liver transplant recipients. Liver Transplantation. 2003;9(4):383-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12682891].
Balbontin FG, Kiberd B, Squires J, et al. Tacrolimus monitoring by simplified sparse sampling under the concentration time curve. Transplant Proc. 2003;35(7):2445-8. Excluded because MPA not measured in blood. [pmid: 14611982].
Baraldo M, Isola M, Feruglio MT, et al. Therapeutic mycophenolic acid monitoring by means of limited sampling strategy in orthotopic heart transplant patients. Transplant Proc. 2005;37(5):2240-3. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15964387].
Barcena R, Oton E, Barreales M, et al. Scarce Influence of Corticosteroid Boluses on Long-Term Viral Load and Liver Histology in Transplanted Patients With Recurrent Hepatitis C. Transplant Proc. 2006;38(8):2502-4. Excluded because MPA not measured in blood. [pmid: 17097981].
Barten MJ, Rahmel A, Chang H, et al. Assessment of immunosuppression by lymphocyte functions in human blood. Transplant Proc. 2002;34(7):2876-7. Excluded because does not report on humans with a solid organ transplant. [pmid: 12431640].
Barten MJ, Rahmel A, Garbade J, et al. Pharmacodynamic monitoring of the conversion of cyclosporine to tacrolimus in heart and lung transplant recipients. Transplant Proc. 2005;37(10):4532-4. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16387162].
Barten MJ, Rahmel A, Garbade J, et al. C0h/C2h monitoring of the pharmacodynamics of cyclosporin plus mycophenolate mofetil in human heart transplant recipients. Transplant Proc. 2005;37(2):1360-1. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15848720].
Barton TD, Blumberg EA, Doyle A, et al. A prospective cross-sectional study of BK virus infection in non-renal solid organ transplant recipients with chronic renal dysfunction. Transplant Infectious Disease. 2006;8(2):102-7. Excluded because MPA not measured in blood. [pmid: 16734633].
Beaulieu AJ, Lapane KL, Gohh RY, et al. Short-term reproducibility of total homocysteine determinations in stable renal transplant recipients. Transplant Proc. 1999;31(5):2121-3. Excluded because MPA not measured in blood. [pmid: 10455988].
Beaunoyer M, Busque S, St Louis G, et al. Low-dose tacrolimus, trough-monitored mycophenolate mofetil, and planned steroid withdrawal for cadaveric kidney transplantation: a single center experience. Transplant Proc. 2002;34(5):1694-5. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12176540].
Belev B, Simeonov P, Popov R, et al. First observations in our country on the administration of mycophenolate mofetill (cellcept) in patients with translplanted kidney. Nephrolgy, Hemodialysis, Transplantation. 1999;5(1):45-6. Excluded because not published in English.
Benech H, Hascoet S, Furlan V, et al. Development and validation of an LC/MS/MS assay for mycophenolic acid in human peripheral blood mononuclear cells. J Chromatogr B: Analyt Technol Biomed Life Sci. 2007;853(12):168-74. Excluded because not a full report of an included study type.
Berger N, Guggenbichler S, Steurer W, et al. Bloodstream infection following 217 consecutive systemic-enteric drained pancreas transplants. BMC Infect Dis. 2006;6:127. Excluded because MPA not measured in blood. [pmid: 16895603]. [pmcid: 1570140].
Bestetti RB, Souza TR, Lima MF, et al. Effects of a mycophenolate mofetil-based immunosuppressive regimen in Chagas' heart transplant recipients [2]. Transplantation. 2007;84(3):441-2. Excluded because MPA not measured in blood. [pmid: 17700175].
Bestetti RB, Souza TR, Lima MF, et al. Effects of a mycophenolate mofetil-based immunosuppressive regimen in Chagas' heart transplant recipients. Transplantation. 2007;84(3):441-2. Excluded because not a full report of an included study type. [pmid: 17700175].
Bogusz MJ, Enazi EA, Hassan H, et al. Simultaneous LC-MS-MS determination of cyclosporine A, tacrolimus, and sirolimus in whole blood as well as mycophenolic acid in plasma using common pretreatment procedure. J Chromatogr B Analyt Technol Biomed Life Sci. 2007;850(12):471-80. Excluded because does not report on humans with a solid organ transplant.
Bohler T, Nolting J, Kamar N, et al. Validation of immunological biomarkers for the pharmacodynamic monitoring of immunosuppressive drugs in humans. Ther Drug Monit. 2007;29(1):77-86. Excluded because MPA not measured in blood. [pmid: 17304154].
Boldt A, Barten MJ, Sagner A, et al. The influence of immunosuppressive drugs on T- and B-cell apoptosis via p53-mediated pathway in vitro and in vivo. Transplantation. 2006;82(3):422-7. Excluded because MPA not measured in blood. [pmid: 16906043].
Borrows R, Chusney G, Loucaidou M, et al. Clinical outcomes of renal transplantation using liquid chromatographic monitoring of tacrolimus. Ther Drug Monit. 2006;28(2):269-73. Excluded because MPA not measured in blood. [pmid: 16628143].
Borrows R, Chusney G, Loucaidou M, et al. The magnitude and time course of changes in mycophenolic acid 12-hour predose levels during antibiotic therapy in mycophenolate mofetil-based renal transplantation. Ther Drug Monit. 2007;29(1):122-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17304160].
Borrows R, Chusney G, Loucaidou M, et al. Analysis of factors influencing tacrolimus levels and immunoassay bias in renal transplantation. J Clin Pharmacol. 2007;47(8):1035-42. Excluded because MPA not measured in blood. [pmid: 17660485].
Bravo Soto JA, Esteban De La Rosa RJ, Luna Del Castillo JD, et al. Effect of mycophenolate mofetil regimen on peripheral blood lymphocyte subsets in kidney transplant recipients. Transplant Proc. 2003;35(4):1355-9. Excluded because MPA not measured in blood. [pmid: 12826158].
Broeders N, Wissing KM, Crusiaux A, et al. Mycophenolate mofetil, together with cyclosporin A, prevents anti-OKT3 antibody response in kidney transplant recipients. J Am Soc Nephrol. 1998;9(8):1521-5. Excluded because MPA not measured in blood. [pmid: 9697676].
Brown NW, Aw MM, Mieli-Vergani G, et al. Mycophenolic acid and mycophenolic acid glucuronide pharmacokinetics in pediatric liver transplant recipients: effect of cyclosporine and tacrolimus comedication. Ther Drug Monit. 2002;24(5):598-606. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12352931].
Brunet M, Oppenheimer F, Martorell J, et al. Mycophenolic acid monitoring: evaluation of the EMIT MPA immunoassay in kidney and lung transplantation. Transplant Proc. 1999;31(6):2275-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 10500574].
Brunet M, Millan O, Jimenez O, et al. New concepts in cyclosporine pharmacokinetic and dynamic monitoring: the impact of concomitant immunosuppression on target C2 concentrations. Transplant Proc. 2004;36(2:Suppl):Suppl-441S. Excluded because MPA levels not associated with any clinical outcomes.
Brunet M, Crespo M, Millan O, et al. Pharmacokinetics and pharmacodynamics in renal transplant recipients under treatment with cyclosporine and myfortic. Transplant Proc. 2007;39(7):2160-2. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17889124].
Buchler M, Lebranchu Y, Beneton M, et al. Higher exposure to mycophenolic acid with sirolimus than with cyclosporine cotreatment. Clin Pharmacol Ther. 2005;78(1):34-42. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16003290].
Budde K, Braun KP, Glander P, et al. Pharmacodynamic monitoring of mycophenolate mofetil in stable renal allograft recipients. Transplant Proc. 2002;34(5):1748-50. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12176561].
Budde K, Knoll G, Curtis J, et al. Safety and efficacy after conversion from mycophenolate mofetil to enteric-coated mycophenolate sodium: results of a 1-year extension study. Transplant Proc. 2005;37(2):912-5. Excluded because MPA not measured in blood. [pmid: 15848573].
Budde K, Knoll G, Curtis J, et al. Long-term safety and efficacy after conversion of maintenance renal transplant recipients from mycophenolate mofetil (MMF) to enteric-coated mycophenolate sodium (EC-MPA, myfortic). Clin Nephrol. 2006;66(2):103-11. Excluded because MPA not measured in blood. [pmid: 16939066].
Budde K, Glander P, Kramer BK, et al. Conversion from mycophenolate mofetil to enteric-coated mycophenolate sodium in maintenance renal transplant recipients receiving tacrolimus: clinical, pharmacokinetic, and pharmacodynamic outcomes. Transplantation. 2007;83(4):417-24. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17318074].
Budde K, Bauer S, Hambach P. Erratum: Pharmacokinetic and pharmacodynamic comparison of enteric-coated mycophenolate sodium and mycophenolate mofetil in maintenance renal transplant patients (Am J Transplant 7, 4, (888–898) DOI:10.1111/j.1600-6143.2007.01693.x). Am J Transplant 2007;(8):2057 Excluded because not a full report of an included study type
Budde K, Tedesco-Silva H, Pestana JM, et al. Enteric-coated mycophenolate sodium provides higher mycophenolic acid predose levels compared with mycophenolate mofetil: implications for therapeutic drug monitoring. Ther Drug Monit. 2007;29(3):381-4. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17529899].
Budde K, Bauer S, Hambach P, et al. Pharmacokinetic and pharmacodynamic comparison of enteric-coated mycophenolate sodium and mycophenolate mofetil in maintenance renal transplant patients. Am J Transplant. 2007;7(4):888-98. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17391132].
Bullingham R, Monroe S, Nicholls A, et al. Pharmacokinetics and bioavailability of mycophenolate mofetil in healthy subjects after single-dose oral and intravenous administration. J Clin Pharmacol. 1996;36(4):315-24. Excluded because does not report on humans with a solid organ transplant. [pmid: 8728345].
Bunnapradist S, Danovitch GM. Minimizing ciclosporin in renal transplant recipients on daclizumab, mycophenolate and steroids. Nature Clinical Practice Nephrology. 2007;3(8):426-7. Excluded because not a full report of an included study type.
Butcher JA, Hariharan S, Adams MB, et al. Renal transplantation for end-stage renal disease following bone marrow transplantation: A report of six cases, with and without immunosuppression. Clin Transplant. 1999;13(4):330-5. Excluded because not a full report of an included study type. [pmid: 10485375].
Calvo N, Sanchez-Fructuoso AI, Conesa J, et al. Renal Transplant Patients With Gastrointestinal Intolerability to Mycophenolate Mofetil: Conversion to Enteric-Coated Mycophenolate Sodium. Transplant Proc. 2006;38(8):2396-7. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17097945].
Cantarovich M, Giannetti N, Cecere R. Impact of cyclosporine 2-h level and mycophenolate mofetil dose on clinical outcomes in de novo heart transplant patients receiving anti-thymocyte globulin induction. Clin Transplant. 2003;17(2):144-50. Excluded because MPA not measured in blood. [pmid: 12709082].
Casas RV, Lopez AV, Rey JLN, et al. Mycophenolic Acid Reaches Therapeutic Levels Whereas Mycophenolate Mofetil Does Not. Transplant Proc. 2006;38(8):2400-1. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17097947].
Cattaneo D, Perico N, Gaspari F, et al. Glucocorticoids interfere with mycophenolate mofetil bioavailability in kidney transplantation. Kidney Int. 2002;62(3):1060-7. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12164891].
Cattaneo D, Merlini S, Pellegrino M, et al. Therapeutic drug monitoring of sirolimus: effect of concomitant immunosuppressive therapy and optimization of drug dosing. Am J Transplant. 2004;4(8):1345-51. Excluded because MPA not measured in blood. [pmid: 15268738].
Cattaneo D, Merlini S, Zenoni S, et al. Influence of co-medication with sirolimus or cyclosporine on mycophenolic acid pharmacokinetics in kidney transplantation. Am J Transplant. 2005;5(12):2937-44. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16303008].
Ceglarek U, Casetta B, Lembcke J, et al. Inclusion of MPA and in a rapid multi-drug LC-tandem mass spectrometric method for simultaneous determination of immunosuppressants. Clin Chim Acta. 2006;373(12):168-71. Excluded because not a full report of an included study type. [pmid: 16806142].
Chen H, Peng C, Yu Z, et al. Pharmacokinetics of mycophenolic acid and determination of area under the curve by abbreviated samplingstrategy in Chinese liver transplant recipients. Clin Pharmacokinet. 2007;46(2):175-85. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17253887].
Chen YH, Zheng KL, Chen LZ, et al. Clinical pharmacokinetics of tacrolimus after the first oral administration in combination with mycophenolate mofetil and prednisone in Chinese renal transplant recipients. Transplant Proc. 2005;37(10):4246-50. Excluded because MPA not measured in blood. [pmid: 16387090].
Chenhsu RY, Wu YM, Min DI, et al. Effects of mycophenolate mofetil on hematocrit after renal transplantation. Ann Pharmacother. 2002;36(9):1479-80. Excluded because not a full report of an included study type. [pmid: 12196073].
Cho EK, Han DJ, Kim SC, et al. Pharmacokinetic study of mycophenolic acid in Korean kidney transplant patients. J Clin Pharmacol. 2004;44(7):743-50. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15199079].
Cibrik D, Meier-Kriesche HU, Bresnahan B, et al. Renal function with cyclosporine C2 monitoring, enteric-coated mycophenolate sodium and basiliximab: a 12-month randomized trial in renal transplant recipients. Clin Transplant. 2007;21(2):192-201. Excluded because MPA not measured in blood. [pmid: 17425744].
Cremers S, Schoemaker R, Scholten E, et al. Characterizing the role of enterohepatic recycling in the interactions between mycophenolate mofetil and calcineurin inhibitors in renal transplant patients by pharmacokinetic modelling. Br J Clin Pharmacol. 2005;60(3):249-56. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16120063]. [pmcid: 1884762].
Cussonneau X, Bolon-Larger M, Prunet-Spano C, et al. Relationship between MPA free fraction and free MPAG concentrations in heart transplant recipients based on simultaneous HPLC quantification of the target compounds in human plasma. J Chromatogr B Analyt Technol Biomed Life Sci. 2007;852(12):674-8. Excluded because MPA levels not associated with any clinical outcomes.
Czock D, Rasche FM, Carius A, et al. Pharmacokinetics and pharmacodynamics of mycophenolic acid after enteric-coated mycophenolate versus mycophenolate mofetil in patients with progressive IgA nephritis. J Clin Pharmacol. 2007;47(7):850-9. Excluded because does not report on humans with a solid organ transplant. [pmid: 17526858].
Dall'Amico R, Ghiggeri G, Carraro M, et al. Prediction and treatment of recurrent focal segmental glomerulosclerosis after renal transplantation in children. Am J Kidney Dis. 1999;34(6):1048-55. Excluded because MPA not measured in blood. [pmid: 10585314].
David-Neto E, Pereira Araujo LM, Sumita NM, et al. Mycophenolic acid pharmacokinetics in stable pediatric renal transplantation. Pediatr Nephrol. 2003;18(3):266-72. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12644921].
David-Neto E, Pereira LM, Kakehashi E, et al. The need of mycophenolic acid monitoring in long-term renal transplants. Clin Transplant. 2005;19(1):19-25. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15659129].
De Geest S, Denhaerynck K, Schafer-Keller P, et al. Supporting medication adherence in renal transplantation - The SMART study. Swiss Medical Weekly. 2007;137(SUPPL 155):125S-7S. Excluded because MPA not measured in blood. [pmid: 17874516].
Devyatko E, Ploner M, Zuckermann A, et al. Value of mycophenolic acid trough level monitoring after lung transplantation. Transplant Proc. 2002;34(5):1881-3. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12176612].
Devyatko E, Zuckermann A, Bohdjalian A, et al. Activation of the purine salvage pathway in mononuclear cells of cardiac recipients treated with mycophenolate mofetil. Transplantation. 2006;82(1):113-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16861950].
Dharancy S, Hulin A, Declerck N, et al. Mycophenolic acid (MPA) AUC(0–12H) in stable liver transplant patients treated with a monotherapy of mycophenolate mofetil (MMF) for calcineurin inhibitors (CNI) induced nephrotoxicity. Hepatology. 2006;44(4, Suppl. 1):406A-7A. Excluded because not a full report of an included study type.
Di Benedetto F, Di Sandro S, De Ruvo N, et al. Sirolimus Monotherapy in Liver Transplantation. Transplantat Proc. 2007;39(6):1930-2. Excluded because MPA not measured in blood.
Diekmann F, Campistol JM, Saval N, et al. Sequential quadruple immunosuppression including sirolimus in extended criteria and nonheartbeating donor kidney transplantation. Transplantation. 2007;84(3):429-32. Excluded because not a full report of an included study type. [pmid: 17700171].
Djebli N, Picard N, Rerolle JP, et al. Influence of the UGT2B7 promoter region and exon 2 polymorphisms and comedications on Acyl-MPAG production in vitro and in adult renal transplant patients. Pharmacogenet Genomics. 2007;17(5):321-30. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17429314].
Doria C, Fraser N, Ramirez CB, et al. Use of EC-MPS (MYFORTIC (R), enteric coated mycophenolate sodium) as part of immunosuppression regimen in liver transplant patients suffering from intestinal intolerance and/or poor quality of life related to the use mycophenolate mofetil (MMF). Hepatology. 2006;44(4, Suppl. 1):411A-2A. Excluded because not a full report of an included study type.
Dosch AO, Ehlermann P, Koch A, et al. A comparison of measured trough levels and abbreviated AUC estimation by limited sampling strategies for monitoring mycophenolic acid exposure in stable heart transplant patients receiving cyclosporin A-containing and cyclosporin A-free immunosuppressive regimens. Clin Ther. 2006;28(6):893-905. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16860172].
Drognitz O, Donauer J, Kamgang J, et al. Living-donor kidney transplantation: The Freiburg experience. Langenbecks Arch Surg. 2007;392(1):23-33. Excluded because MPA not measured in blood. [pmid: 16924533].
Ducloux D, Motte G, Billerey C, et al. Cyclosporin withdrawal with concomitant conversion from azathioprine to mycophenolate mofetil in renal transplant recipients with chronic allograft nephropathy: a 2-year follow-up. Transpl Int. 2002;15(8):387-92. Excluded because MPA not measured in blood. [pmid: 12221456].
El Haggan W, Ficheux M, Debruyne D, et al. Pharmacokinetics of mycophenolic acid in kidney transplant patients receiving sirolimus versus cyclosporine. Transplant Proc. 2005;37(2):864-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15848558].
Engelbertink R, Smak GP, Hesse C, et al. High mycophenolic acid area under-the-curve values in renal transplant recipients on long-term mycophenolate mofetil treatment. Transplant Proc. 2002;34(7):2983-4. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12431677].
Ensom MH, Partovi N, Decarie D, et al. Pharmacokinetics and protein binding of mycophenolic acid in stable lung transplant recipients. Ther Drug Monit. 2002;24(2):310-4. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 11897977].
Ensom MH, Partovi N, Decarie D, et al. Mycophenolate pharmacokinetics in early period following lung or heart transplantation. Ann Pharmacother. 2003;37(12):1761-7. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 14632536].
Esmatjes E, Flores L, Vidal M, et al. Hypoglycaemia after pancreas transplantation: Usefulness of a continuous glucose monitoring system. Clin Transplant. 2003;17(6):534-8. Excluded because MPA not measured in blood. [pmid: 14756270].
Ettenger R, Bartosh S, Choi L, et al. Pharmacokinetics of enteric-coated mycophenolate sodium in stable pediatric renal transplant recipients. Pediatr Transplant. 2005;9(6):780-7. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16269051].
Fatela-Cantillo D, Hinojosa-Perez R, Peralvo-Rodriguez MI, et al. Pharmacokinetic Evaluation of Mycophenolic Acid Profiles During the Period Immediately Following an Orthotopic Liver Transplant. Transplant Proc. 2006;38(8):2482-5. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17097975].
Fernandez A, Martins J, Villlafruela JJ, et al. Variability of mycophenolate mofetil trough levels in stable kidney transplant patients. Transplant Proc. 2007;39(7):2185-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17889132].
Fernandez A, Marcen R, Pascual J, et al. Mycophenolate mofetil levels in stable kidney transplant recipients. Transplant Proc. 2007;39(7):2182-4. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17889131].
Ferraris JR, Ghezzi L, Waisman G, et al. Potential cardiovascular risk factors in paediatric renal transplant recipients. Pediatr Nephrol. 2006;21(1):119-25. Excluded because MPA not measured in blood. [pmid: 16252106].
Figueras J, Prieto M, Bernardos A, et al. Daclizumab induction and maintenance steroid-free immunosuppression with mycophenolate mofetil and tacrolimus to prevent acute rejection of hepatic allografts. Transpl Int. 2006;19(8):641-8. Excluded because MPA not measured in blood. [pmid: 16827681].
Filler G, Zimmering M, Mai I. Pharmacokinetics of mycophenolate mofetil are influenced by concomitant immunosuppression. Pediatr Nephrol. 2000;14(2):100-4. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 10684356].
Filler G, Lepage N, Delisle B, et al. Effect of cyclosporine on mycophenolic acid area under the concentration-time curve in pediatric kidney transplant recipients. Ther Drug Monit. 2001;23(5):514-9. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 11591896].
Filler G, Feber J. The transplanted child: New immunosuppressive agents and the need for pharmacokinetic monitoring. Paediatrics and Child Health. 2002;7(8):525-32. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 20046464].
Filler G, Feber J, Lepage N, et al. Universal approach to pharmacokinetic monitoring of immunosuppressive agents in children. Pediatr Transplant. 2002;6(5):411-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12390429].
Filler G. Abbreviated mycophenolic acid AUC from C0, C1, C2, and C4 is preferable in children after renal transplantation on mycophenolate mofetil and tacrolimus therapy. Transpl Int. 2004;17(3):120-5. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 14749919].
Filler G, Foster J, Berard R, et al. Age-dependency of mycophenolate mofetil dosing in combination with tacrolimus after pediatric renal transplantation. Transplant Proc. 2004;36(5):1327-31. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15251324].
Filler G, De Barros VR, Jagger JE, et al. Cyclosporin twice or three times daily dosing in pediatric transplant patients - It is not the same!. Pediatr Transplant. 2006;10(8):953-6. Excluded because MPA not measured in blood. [pmid: 17096765].
Filler G. Optimization of Immunosuppressive Drug Monitoring in Children. Transplant Proc. 2007;39(4):1241-3. Excluded because not a full report of an included study type. [pmid: 17524944].
Firpi RJ, Nelson DR, Davis GL. Lack of antiviral effect of a short course of mycophenolate mofetil in patients with chronic hepatitis C virus infection. Liver Transpl. 2003;9(1):57-61. Excluded because MPA not measured in blood. [pmid: 12514774].
Flechner SM, Goldfarb D, Modlin C, et al. Kidney transplantation without calcineurin inhibitor drugs: a prospective, randomized trial of sirolimus versus cyclosporine. Transplantation. 2002;74(8):1070-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12438948].
Flechner SM, Goldfarb D, Solez K, et al. Kidney transplantation with sirolimus and mycophenolate mofetil-based immunosuppression: 5-year results of a randomized prospective trial compared to calcineurin inhibitor drugs. Transplantation. 2007;83(7):883-92. Excluded because MPA not measured in blood. [pmid: 17460558].
Fleming DH, Mathew BS, John GT, et al. A six-hour extrapolated sampling strategy for monitoring mycophenolic acid in renal transplant patients in the Indian subcontinent. J Postgrad Med. 2006;52(4):248-52. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17102540].
Folkmane I, Bernarde K, Bicans J, et al. Beneficial effects of low-toxicity regimens with MMF in renal recipients with late allograft dysfunction. Transplant Proc. 2003;35(2):789-90. Excluded because MPA not measured in blood. [pmid: 12644138].
Funch DP, Ko HH, Travasso J, et al. Posttransplant lymphoproliferative disorder among renal transplant patients in relation to the use of mycophenolate mofetil. Transplantation. 2005;80(9):1174-80. Excluded because MPA not measured in blood. [pmid: 16314782].
Galiwango P, Delgado D, Ross H. Dose reduction of MMF due to gastrointestinal intolerance is associated with increased rejection in heart transplant recipients. J Heart Lung Transplant. 2007;26(2, Suppl. S):S70-S71. Excluded because not a full report of an included study type.
Gallon LG, Winoto J, Chhabra D, et al. Long-term renal transplant function in recipient of simultaneous kidney and pancreas transplant maintained with two prednisone-free maintenance immunosuppressive combinations: acrolimus/mycophenolate mofetil versus tacrolimus/sirolimus. Transplantation. 2007;83(10):1324-9. Excluded because MPA not measured in blood. [pmid: 17519781].
Garcia CD, Bittencourt VB, Tumelero A, et al. Plasmapheresis for recurrent posttransplant focal segmental glomerulosclerosis. Transplant Proc. 2006;38(6):1904-5. Excluded because MPA not measured in blood. [pmid: 16908318].
Garcia R, Machado PG, Felipe CR, et al. Exploratory calcineurin inhibitor-free regimens in living-related kidney transplant recipients. Braz J Med Biol Res. 2007;40(4):457-65. Excluded because MPA not measured in blood. [pmid: 17401488].
Garlicki M, Kolcz J, Rudzinski P, et al. Myocardial protection for transplantation. Transplant Proc. 1999;31(5):2079-83. Excluded because MPA not measured in blood. [pmid: 10455976].
Gelone DK, Park JM, Lake KD. Lack of an effect of oral iron administration on mycophenolic acid pharmacokinetics in stable renal transplant recipients. Pharmacotherapy. 2007;27(9):1272-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17723081].
Genctoy G, Kahraman S, Arici M, et al. The role of proinflammatory cytokine gene polymorphisms for development of insulin resistance after renal transplantation. Transplant Proc. 2006;38(2):521-8. Excluded because MPA not measured in blood. [pmid: 16549165].
Ghafari A, Makhdoomi K, Ahmadpour P, et al. Low-Dose Versus High-Dose Cyclosporine Induction Protocols in Renal Transplantation. Transplantation Proceedings 39(4)()(pp 1219–1222), 2007 Date of Publication: May 2007 2007;(4):1219–22. Excluded because MPA not measured in blood
Ghio L, Ferraresso M, Vigano SM, et al. Mycophenolate mofetil pharmacokinetic monitoring in pediatric kidney transplant recipients. Transplant Proc. 2005;37(2):856-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15848555].
Ghobrial RM, Holt CD, Sievers TM, et al. Mycophenolate mofetil in liver transplantation for hepatitis C: effect on recurrence and pharmacokinetics. Am J Transplant. 2004;4(Suppl 8):598. Excluded because not a full report of an included study type.
Gimenez F, Foeillet E, Bourdon O, et al. Evaluation of pharmacokinetic interactions after oral administration of mycophenolate mofetil and valaciclovir or aciclovir to healthy subjects. Clin Pharmacokinet. 2004;43(10):685-92. Excluded because does not report on humans with a solid organ transplant. [pmid: 15244498].
Glander P, Hambach P, Braun KP, et al. Effect of mycophenolate mofetil on IMP dehydrogenase after the first dose and after long-term treatment in renal transplant recipients. Int J Clin Pharmacol Ther. 2003;41(10):470-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 14703953].
Glander P, Hambach P, Braun KP, et al. Pre-transplant inosine monophosphate dehydrogenase activity is associated with clinical outcome after renal transplantation. Am J Transplant. 2004;4(12):2045-51. Excluded because MPA not measured in blood. [pmid: 15575908].
Goel M, Flechner SM, Zhou L, et al. The influence of various maintenance immunosuppressive drugs on lymphocele formation and treatment after kidney transplantation. J Urol. 2004;171(5):1788-92. Excluded because MPA not measured in blood. [pmid: 15076277].
Goldsmith D, Carrey EA, Edbury S, et al. Mycophenolate mofetil, an inhibitor of inosine monophosphate dehydrogenase, causes a paradoxical elevation of GTP in erythrocytes of renal transplant patients. Clin Sci. 2004;107(1):63-8. Excluded because MPA not measured in blood. [pmid: 14723604].
Gomard-Mennesson E, Ruivard M, Koenig M, et al. Treatment of isolated severe immune hemolytic anaemia associated with systemic lupus erythematosus: 26 Cases. Lupus. 2006;15(4):223-31. Excluded because does not report on humans with a solid organ transplant. [pmid: 16686262].
Gonwa T, Mendez R, Yang HC, et al. Randomized trial of tacrolimus in combination with sirolimus or mycophenolate mofetil in kidney transplantation: results at 6 months. Transplantation. 2003;75(8):1213-20. Excluded because MPA not measured in blood. [pmid: 12717205].
Gonzalez-Roncero FM, Govantes MA, Chaves VC, et al. Influence of Renal Insufficiency on Pharmacokinetics of ACYL-Glucuronide Metabolite of Mycophenolic Acid in Renal Transplant Patients. Transplant Proc. 2007;39(7):2176-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17889129].
Gonzalez MM, Seron D, Garcia DM, et al. Mycophenolate mofetil reduces deterioration of renal function in patients with chronic allograft nephropathy. A follow-up study by the Spanish Cooperative Study Group of Chronic Allograft Nephropathy. Transplantation. 2004;77(2):215-20. Excluded because MPA not measured in blood. [pmid: 14742984].
Goossens VJ, Christiaans MH, Blok MJ, et al. Onset and duration of cytomegalovirus immediate early 1 mRNA expression in the blood of renal transplant recipients. J Med Virol. 2004;72(1):94-101. Excluded because MPA not measured in blood. [pmid: 14635016].
Graff J, Klinkhardt U, Harder S, et al. Immunosuppressive therapy regimen and platelet activation in renal transplant patients. Clin Pharmacol Ther. 2002;72(4):411-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12386643].
Gregoor PJ, De Sevaux RG, Hene RJ, et al. Effect of cyclosporine on mycophenolic acid trough levels in kidney transplant recipients. Transplantation. 1999;68(10):1603-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 10589962].
Griesmacher A, Weigel G, Seebacher G, et al. Inhibition of inosine monophosphate dehydrogenase activity by the plasma of heart transplant recipients receiving mycophenolate mofetil. Adv Exp Med Biol. 1998;431:537-41. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 9598124].
Griesmacher A, Weigel G, Seebacher G, et al. Guanosine-5′-triphosphate increases in red blood cells of heart transplant recipients treated with mycophenolate mofetil. Adv Exp Med Biol. 2000;486:139-43. Excluded because MPA not measured in blood. [pmid: 11783471].
Guleria S, Kamboj M, Singh P, et al. Tacrolimus (Pan Graf) as de Novo Therapy in Renal Transplant Recipients in India. Transplant Proc. 2006;38(7):2029-31. Excluded because MPA not measured in blood. [pmid: 16979989].
Hafiz MM, Faradji RN, Froud T, et al. Immunosuppression and procedure-related complications in 26 patients with type 1 diabetes mellitus receiving allogeneic islet cell transplantation. Transplantation. 2005;80(12):1718-28. Excluded because does not report on humans with a solid organ transplant. [pmid: 16378067].
Halloran P, Mathew T, Tomlanovich S. Erratum: Mycophenolate mofetil in renal allograft recipients: A polled efficacy analysis of three randomized, double-blind, clinical studies in prevention of rejection (Transplantation (January 15, 1997) 63:39 (43–44)). Transplantation. 1997;63(4):618. Excluded because not a full report of an included study type.
Hanto DW, Fecteau AH, Alonso MH, et al. ABO-incompatible liver transplantation with no immunological graft losses using total plasma exchange, splenectomy, and quadruple immunosuppression: evidence for accommodation. Liver Transpl. 2003;9(1):22-30. Excluded because MPA not measured in blood. [pmid: 12514769].
Hariharan S. Case 3: New clinical trials in renal transplantation. Transplantation (Hagerstown). 2003;75(7):1084-7. Excluded because not a full report of an included study type.
Havrdova T, Saudek F, Boucek P, et al. Metabolic effect of sirolimus versus mycophenolate mofetil on pancreatic graft function - a prospective randomised study. Diabetologia. 2006;49(Suppl. 1):150-1. Excluded because not a full report of an included study type.
Hazzan M, Buob D, Labalette M, et al. Assessment of the risk of chronic allograft dysfunction after renal transplantation in a randomized cyclosporine withdrawal trial. Transplantation. 2006;82(5):657-62. Excluded because MPA not measured in blood. [pmid: 16969289].
Hocker B, Weber LT, Bunchman T, et al. Mycophenolate mofetil suspension in pediatric renal transplantation: three-year data from the tricontinental trial. Pediatr Transplant. 2005;9(4):504-11. Excluded because MPA not measured in blood. [pmid: 16048604].
Hohage H, Zeh M, Heck M, et al. Differential effects of cyclosporine and tacrolimus on mycophenolate pharmacokinetics in patients with impaired kidney function. Transplant Proc. 2005;37(4):1748-50. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15919453].
Hricik DE, Anton HA, Knauss TC, et al. Outcomes of African American kidney transplant recipients treated with sirolimus, tacrolimus, and corticosteroids. Transplantation. 2002;74(2):189-93. Excluded because MPA not measured in blood. [pmid: 12151730].
Hubner GI, Eismann R, Sziegoleit W. Drug interaction between mycophenolate mofetil and tacrolimus detectable within therapeutic mycophenolic acid monitoring in renal transplant patients. Ther Drug Monit. 1999;21(5):536-9. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 10519451].
Humar A, Crotteau S, Gruessner A, et al. Steroid minimization in liver transplant recipients: Impact on hepatitis C recurrence and post-transplant diabetes. Clin Transplant. 2007;21(4):526-31. Excluded because MPA not measured in blood. [pmid: 17645714].
Hummel M, Yonan N, Ross H, et al. Pharmacokinetics and variability of mycophenolic acid from enteric-coated mycophenolate sodium compared with mycophenolate mofetil in de novo heart transplant recipients. Clin Transplant. 2007;21(1):18-23. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17302587].
Hutchinson P, Chadban SJ, Atkins RC, et al. Laboratory assessment of immune function in renal transplant patients. Nephrol Dial Transplant. 2003;18(5):983-9. Excluded because MPA not measured in blood. [pmid: 12686675].
Hymes LC, Greenbaum L, Amaral SG, et al. Surveillance renal transplant biopsies and subclinical rejection at three months post-transplant in pediatric recipients. Pediatr Transplant. 2007;11(5):536-9. Excluded because MPA not measured in blood. [pmid: 17631023].
Inoue K, Miura M, Satoh S, et al. Influence of UGT1A7 and UGT1A9 intronic I399 genetic polymorphisms on mycophenolic acid pharmacokinetics in Japanese renal transplant recipients. Ther Drug Monit. 2007;29(3):299-304. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17529886].
Jacobson PA, Green KG, Hering BJ. Mycophenolate mofetil in islet cell transplant: Variable pharmacokinetics but good correlation between total and unbound concentrations. J Clin Pharmacol. 2005;45(8):901-9. Excluded because does not report on humans with a solid organ transplant. [pmid: 16027400].
Jacqz-Aigrain E, Khan SE, Baudouin V, et al. Pharmacokinetics and tolerance of mycophenolate mofetil in renal transplant children. Pediatr Nephrol. 2000;14(2):95-9. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 10684355].
Jain A, Venkataramanan R, Hamad IS, et al. Pharmacokinetics of mycophenolic acid after mycophenolate mofetil administration in liver transplant patients treated with tacrolimus. J Clin Pharmacol. 2001;41(3):268-76. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 11269567].
Jain A, Venkataramanan R, Kwong T, et al. Pharmacokinetics of mycophenolic acid in Liver transplant patients after intravenous and oral administration of mycophenolate mofetil. Liver Transpl. 2007;13(6):791-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17538999].
Jain AB, Hamad I, Zuckerman S, et al. Effect of t-tube clamping on the pharmacokinetics of mycophenolic acid in liver transplant patients on oral therapy of mycophenolate mofetil. Liver Transplantation and Surgery. 1999;5(2):101-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 10071348].
Ji SM, Liu ZH, Chen JS, et al. Rescue Therapy by Immunoadsorption in Combination With Tacrolimus and Mycophenolate Mofetil for C4d-Positive Acute Humoral Renal Allograft Rejection. Transplant Proc. 2006;38(10):3459-63. Excluded because MPA not measured in blood. [pmid: 17175303].
Ji SM, Li LS, Cheng Z, et al. A Single-dose Daclizumab Induction Protocol in Renal Allograft Recipients: A Chinese Single Center Experience. Transplant Proc. 2007;39(5):1396-1401. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17580147].
Jiao Z, Zhong JY, Zhang M, et al. Total and free mycophenolic acid and its 7-O-glucuronide metabolite in Chinese adult renal transplant patients: Pharmacokinetics and application of limited sampling strategies. Eur J Clin Pharmacol. 2007;63(1):27-37. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17093994].
Jiao Z, Shen B, Zhang M, et al. Population pharmacokinetics of mycophenolic acid in Chinese adult renal transplant recipients during the first month after transplantation. Acta Pharmacologica Sinica 2006;27(Suppl. 1): Excluded because not a full report of an included study type
Jirasiritham S, Sumethkul V, Mavichak V, et al. The pharmacokinetics of mycophenolate mofetil in Thai kidney transplant recipients. Transplant Proc. 2004;36(7):2076-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15518751].
Johnson L, Oetting W, Basu S, et al. Pharmacogenetics of mycophenolate in kidney transplantation. Clin Pharmacol Ther. 2007;81(Suppl. 1):S32-S33. Excluded because not a full report of an included study type.
Jorgensen KA, Povlsen JV, Madsen S, et al. Two-hour blood tacrolimus levels are not superior to trough levels as estimates of the area under the curve in tacrolimus-treated renal transplant patients. Transplant Proc. 2002;34(5):1721-2. Excluded because MPA not measured in blood. [pmid: 12176551].
Julasareekul W, Eiam-Ong S, Bejraputra O, et al. Pharmacokinetics of mycophenolic acid in kidney transplant recipients treated with a low dose (1 gram/day) of mycophenolate mofetil. J Med Assoc Thai. 2003;86(8):766-71. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12948276].
Jungraithmayr TC, Wiesmayr S, Staskewitz A, et al. Five-year outcome in pediatric patients with mycophenolate mofetil-based renal transplantation. Transplantation. 2007;83(7):900-5. Excluded because MPA not measured in blood. [pmid: 17460560].
Kagaya H, Inoue K, Miura M, et al. Quantification and 24-hour monitoring of mycophenolic acid by high-performance liquid chromatography in Japanese renal transplant recipients. Yakugaku Zasshi. 2006;126(12):1357-62. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17139160].
Kagaya H, Inoue K, Miura M, et al. Influence of UGT1A8 and UGT2B7 genetic polymorphisms on mycophenolic acid pharmacokinetics in Japanese renal transplant recipients. Eur J Clin Pharmacol. 2007;63(3):279-88. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17211619].
Kagaya H, Inoue K, Miura M, et al. Quantification and 24-hour monitoring of mycophenolic acid by high-performance liquid chromatography in Japanese renal transplant recipients. Yakugaku Zasshi. 2006;126(12):1357-62. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17139160].
Kahan BD. High variability of drug exposure: a biopharmaceutic risk factor for chronic rejection. Transplant Proc. 1998;30(5):1639-41. Excluded because not a full report of an included study type. [pmid: 9723224].
Kamar N, Oufroukhi L, Sallusto F, et al. Impact of mycophenolic acid dose modifications on renal function after kidney transplantation. Exp Clin Transplant. 2006;4(2):510-7. Excluded because MPA not measured in blood. [pmid: 17238849].
Kaplan B, Meier-Kriesche HU, Minnick P, et al. Randomized calcineurin inhibitor cross over study to measure the pharmacokinetics of co-administered enteric-coated mycophenolate sodium. Clin Transplant. 2005;19(4):551-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16008604].
Kato R, Ooi K, Ikura-Mori M, et al. Impairment of mycophenolate mofetil absorption by calcium polycarbophil. J Clin Pharmacol. 2002;42(11):1275-80. Excluded because does not report on humans with a solid organ transplant. [pmid: 12412828].
Kausman JY, Powell HR, Jones CL. Anemia in pediatric renal transplant recipients. Pediatr Nephrol. 2004;19(5):526-30. Excluded because MPA not measured in blood. [pmid: 15007719].
Keogh A. Long-term benefits of mycophenolate mofetil after heart transplantation. Transplantation (Hagerstown). 2005;79(3, Suppl. S):S45-S46. Excluded because MPA not measured in blood.
Keven K, Sahin M, Kutlay S, et al. Immunoglobulin deficiency in kidney allograft recipients: comparative effects of mycophenolate mofetil and azathioprine. Transplant Infectious Disease. 2003;5(4):181-6. Excluded because MPA not measured in blood. [pmid: 14987202].
Khosroshahi HT, Asghari A, Estakhr R, et al. Effects of Azathioprine and Mycophenolate Mofetil-Immunosuppressive Regimens on the Erythropoietic System of Renal Transplant Recipients. Transplant Proc. 2006;38(7):2077-9. Excluded because MPA not measured in blood. [pmid: 16980004].
Khosroshahi HT, Nahali A, Gojazadeh M, et al. Comparison of Transplanted Kidney Function in Patients on Two Different Doses of Mycophenolate Mofetil. Transplant Proc. 2006;38(7):2035-7. Excluded because MPA not measured in blood. [pmid: 16979991].
Kiberd BA, Puthenparumpil JJ, Fraser A, et al. Impact of mycophenolate mofetil loading on drug exposure in the early posttransplant period. Transplant Proc. 2005;37(5):2320-3. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15964408].
Kim MJ, Mayr M, Pechula M, et al. Marked erythrocyte microcytosis under primary immunosuppression with sirolimus. Transpl Int. 2006;19(1):12-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16359372].
Kirsch BM, Haidinger M, Zeyda M, et al. Alemtuzumab (Campath-1H) induction therapy and dendritic cells: Impact on peripheral dendritic cell repertoire in renal allograft recipients. Transpl Immunol. 2006;16(34):254-7. Excluded because MPA not measured in blood. [pmid: 17138063].
Knight RJ, Kerman RH, McKissick E, et al. A pilot study of immunosuppression minimization after pancreas-kidney transplantation utilizing thymoglobulin induction and sirolimus maintenance therapy. Transplant Proc. 2005;37(8):3538-41. Excluded because MPA not measured in blood. [pmid: 16298653].
Kobashigawa JA, Miller LW, Russell SD, et al. Tacrolimus with mycophenolate mofetil (MMF) or sirolimus vs. cyclosporine with MMF in cardiac transplant patients: 1-year report. Am J Transplant. 2006;6(6):1377-86. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16686761].
Kobashigawa JA, Renlund DG, Gerosa G, et al. Similar efficacy and safety of enteric-coated mycophenolate sodium (EC-MPS, myfortic) compared with mycophenolate mofetil (MMF) in de novo heart transplant recipients: Results of a 12-month, single-blind, randomized, parallel-group, multicenter study. J Heart Lung Transplant. 2006;25(8):935-41. Excluded because MPA not measured in blood. [pmid: 16890114].
Kocik M, Malek I, Glagolicova A, et al. The effect of cyclosporin A on the level of big endothelin in patients one year after orthotopic heart transplantation. Transpl Int. 2004;17(2):65-70. Excluded because MPA not measured in blood. [pmid: 14634722].
Kreis H. Worse renal transplant outcomes with sirolimus-mycophenolate than with calcineurin inhibitor regimens. Nature Clinical Practice Nephrology. 2007;3(8):424-5. Excluded because not a full report of an included study type.
Kuriata-Kordek M, Boratynska M, Falkiewicz K, et al. The influence of calcineurin inhibitors on mycophenolic acid pharmacokinetics. Transplant Proc. 2003;35(6):2369-71. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 14529944].
Kuypers DR, Claes K, Evenepoel P, et al. Time-related clinical determinants of long-term tacrolimus pharmacokinetics in combination therapy with mycophenolic acid and corticosteroids: a prospective study in one hundred de novo renal transplant recipients. Clin Pharmacokinet. 2004;43(11):741-62. Excluded because MPA not measured in blood. [pmid: 15301578].
Lage E, Ballesteros S, Mogollon MV, et al. Is It Possible to Reduce the Number of Endomyocardial Biopsies With New Immunosuppressive Drugs?. Transplant Proc. 2006;38(8):2544-6. Excluded because MPA not measured in blood. [pmid: 17097996].
Land W, Schneeberger H, Weiss M, et al. Mycophenolate mofetil monotherapy: an optimal, safe, and efficacious immunosuppressive maintenance regimen in kidney transplant patients. Transplant Proc. 2001;33(4:Suppl):Suppl-35S. Excluded because MPA not measured in blood.
Langman LJ, LeGatt DF, Halloran PF, et al. Pharmacodynamic assessment of mycophenolic acid-induced immunosuppression in renal transplant recipients. Transplantation. 1996;62(5):666-72. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 8830834].
Langrehr JM, Klupp J, Glanemann M, et al. Long-term results of mycophenolate mofetil as part of immunosuppressive induction therapy after liver transplantation. Clin Transplant. 2006;20(3):272-83. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16824141].
Le Guellec C, Buchler M, Giraudeau B, et al. Simultaneous estimation of cyclosporin and mycophenolic acid areas under the curve in stable renal transplant patients using a limited sampling strategy. Eur J Clin Pharmacol. 2002;57(11):805-11. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 11868803].
Le Guellec C, Bourgoin H, Buchler M, et al. Population pharmacokinetics and Bayesian estimation of mycophenolic acid concentrations in stable renal transplant patients. Clin Pharmacokinet. 2004;43(4):253-66. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15005639].
Leogrande D, Teutonico A, Ranieri E, et al. Monitoring biological action of rapamycin in renal transplantation. Am J Kidney Dis. 2007;50(2):314-25. Excluded because MPA not measured in blood. [pmid: 17660033].
Lessan-Pezeshki M. Pregnancy after renal transplantation: Points to consider. Nephrol Dial Transplant. 2002;17(5):703-7. Excluded because not a full report of an included study type. [pmid: 11981050].
Lessan-Pezeshki M, Amirzargar A, Fathi A, et al. Value of pretransplantation cytokine profiles for predicting acute rejection in renal transplant recipients. Transplant Proc. 2005;37(7):2982-4. Excluded because MPA not measured in blood. [pmid: 16213280].
Li H, Tanaka K, Chhabra A, et al. Vascular remodeling 1 year after cardiac transplantation. J Heart Lung Transplant. 2007;26(1):56-62. Excluded because MPA not measured in blood. [pmid: 17234518].
Liang MZ, Lu YP, Nan F, et al. Pharmacokinetics of Mycophenolic Acid and Its Glucuronide After a Single and Multiple Oral Dose of Mycophenolate Mofetil in Chinese Renal Transplantation Recipients. Transplant Proc. 2006;38(7):2044-7. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16979994].
Lira MG, Provezza L, Malerba G, et al. Glutathione S-transferase and CYP1A1 gene polymorphisms and non-melanoma skin cancer risk in Italian transplanted patients. Exp Dermatol. 2006;15(12):958-65. Excluded because MPA not measured in blood. [pmid: 17083362].
Loinaz C, Kato T, Nishida S, et al. Bacterial infections after intestine and multivisceral transplantation. The experience of the University of Miami (1994-2001). Hepatogastroenterology. 2006;53(68):234-42. Excluded because MPA not measured in blood. [pmid: 16608031].
Lorenz M, Wolzt M, Weigel G, et al. Ferrous sulfate does not affect mycophenolic acid pharmacokinetics in kidney transplant patients. Am J Kidney Dis. 2004;43(6):1098-103. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15168391].
Mai I, Stormer E, Bauer S, et al. Impact of St John's wort treatment on the pharmacokinetics of tacrolimus and mycophenolic acid in renal transplant patients. Nephrol Dial Transplant. 2003;18(4):819-22. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12637655].
Mardigyan V, Giannetti N, Cecere R, et al. Best single time points to predict the area-under-the-curve in long-term heart transplant patients taking mycophenolate mofetil in combination with cyclosporine or tacrolimus. J Heart Lung Transplant. 2005;24(10):1614-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16210138].
Mardigyan V, Tchervenkov J, Metrakos P, et al. Best single time points as surrogates to the tacrolimus and mycophenolic acid area under the curve in adult liver transplant patients beyond 12 months of transplantation. Clin Ther. 2005;27(4):463-9. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15922819].
Margolis DM, Kewn S, Coull JJ, et al. The addition of mycophenolate mofetil to antiretroviral therapy including abacavir is associated with depletion of intracellular deoxyguanosine triphosphate and a decrease in plasma HIV-1 RNA. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2002;31(1):45-9. Excluded because does not report on humans with a solid organ transplant.
Martins L, Pedroso S, Henriques AC, et al. Simultaneous pancreas-kidney transplantation: five-year results from a single center. Transplant Proc. 2006;38(6):1929-32. Excluded because MPA not measured in blood. [pmid: 16908326].
Masri MA, Rizk S, Attia MLE, et al. Bioavailability of a New Generic Formulation of Mycophenolate Mofetil MMF 500 Versus CellCept in Healthy Adult Volunteers. Transplantation Proceedings 39(4)()(pp 1233–1236), 2007 Date of Publication: May 2007 2007;(4):1233–6. Excluded because does not report on humans with a solid organ transplant
Matas AJ, Kandaswamy R, Humar A, et al. Long-term immunosuppression, without maintenance prednisone, after kidney transplantation. Ann Surg. 2004;240(3):510-7. Excluded because MPA not measured in blood. [pmid: 15319722]. [pmcid: 1356441].
Mathew JM, Carreno M, Fuller L, et al. In vitro immunogenicity of cadaver donor bone marrow cells used for the induction of allograft acceptance in clinical transplantation. Transplantation. 1999;68(8):1172-80. Excluded because not a full report of an included study type. [pmid: 10551647].
Matthew TH. Erratum: A blinded, long-term, randomized multicenter study of mycophenolate mofetil in cadaveric renal transplantation: Results at three years Transplantation (June 15, 1998) 65:11 (1450)). Transplantation. 1998;66(6):817. Excluded because not a full report of an included study type.
McDiarmid SV. Mycophenolate mofetil in liver transplantation. Clin Transplant 1996;10(1:Pt 2):t-5 Excluded because MPA levels not associated with any clinical outcomes
Meier-Kriesche HU, Steffen BJ, Hochberg AM, et al. Mycophenolate mofetil versus azathioprine therapy is associated with a significant protection against long-term renal allograft function deterioration. Transplantation. 2003;75(8):1341-6. Excluded because MPA not measured in blood. [pmid: 12717227].
Meiser B, Van Cleemput J, Perez Villa F, et al. Trough level adapted mmf in combination with either tacrolimus or cyclosporine - The Pan-Eu-HTx trial. J Heart Lung Transplant 2007;26(2, Suppl. S) Excluded because not a full report of an included study type
Meiser BM, Groetzner J, Kaczmarek I, et al. Tacrolimus or cyclosporine: which is the better partner for mycophenolate mofetil in heart transplant recipients?. Transplantation. 2004;78(4):591-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15446320].
Mendizabal S, Zamora I, Berbel O, et al. Mycophenolate mofetil in steroid/cyclosporine-dependent/resistant nephrotic syndrome. Pediatr Nephrol. 2005;20(7):914-9. Excluded because does not report on humans with a solid organ transplant. [pmid: 15891923].
Miladipour AH, Ghods AJ, Nejadgashti H. Effect of mycophenolate mofetil on the prevention of acute renal allograft rejection. Transplant Proc. 2002;34(6):2089-90. Excluded because MPA not measured in blood. [pmid: 12270325].
Millan O, Oppenheimer F, Brunet M, et al. Assessment of mycophenolic acid-induced immunosuppression: a new approach. Clin Chem. 2000;46(9):1376-83. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 10973868].
Millan O, Brunet M, Campistol JM, et al. Pharmacodynamic approach to immunosuppressive therapies using calcineurin inhibitors and mycophenolate mofetil. Clin Chem. 2003;49(11):1891-9. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 14578321].
Minz M, Sharma A, Heer M. Comparison of Enteric-Coated Mycophenolate Sodium With Mycophenolate Mofetil in Living Renal Allograft Transplantation. Transplant Proc. 2006;38(7):2041-3. Excluded because MPA not measured in blood. [pmid: 16979993].
Misiakos EP, Weppler D, Neto AB, et al. The current status of small bowel transplantation: The experience at the University of Miami. Archives of Gastroenterohepatology. 1998;17(2):37-44. Excluded because MPA not measured in blood.
Montanaro D, Gropuzzo M, Tulissi P, et al. Effects of mycophenolate mofetil and azathioprine on the erythropoietin production in renal transplant recipients. Transplant Proc. 2001;33(78):3253-5. Excluded because MPA not measured in blood. [pmid: 11750393].
Montejo M, iz ML, Zarraga S, et al. Case reports. Infection due to Scedosporium apiospermum in renal transplant recipients: A report of two cases and literature review of central nervous system and cutaneous infections by Pseudallescheria boydii/Sc. apiospermum. Mycoses. 2002;45(910):418-27. Excluded because not a full report of an included study type. [pmid: 12421295].
Moreno JM, Rubio E, Gomez A, et al. Effectiveness and safety of mycophenolate mofetil as monotherapy in liver transplantation. Transplant Proc. 2003;35(5):1874-6. Excluded because MPA not measured in blood. [pmid: 12962831].
Morissette P, Albert C, Busque S, et al. In vivo higher glucuronidation of mycophenolic acid in male than in female recipients of a cadaveric kidney allograft and under immunosuppressive therapy with mycophenolate mofetil. Ther Drug Monit. 2001;23(5):520-5. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 11591897].
Morris RG, Russ GR, Cervelli MJ, et al. Comparison of trough, 2-hour, and limited AUC blood sampling for monitoring cyclosporin (Neoral) at day 7 post-renal transplantation and incidence of rejection in the first month. Ther Drug Monit. 2002;24(4):479-86. Excluded because MPA not measured in blood. [pmid: 12142630].
Mourad G, Karras A, Kamar N, et al. Renal function with delayed or immediate cyclosporine microemulsion in combination with enteric-coated mycophenolate sodium and steroids: results of follow up to 30 months posttransplant. Clin Transplant. 2007;21(3):295-300. Excluded because MPA not measured in blood. [pmid: 17488375].
Mucha K, Foroncewicz B, Paczek L, et al. 36-month follow-up of 75 renal allograft recipients treated with steroids, tacrolimus, and azathioprine or mycophenolate mofetil. Transplant Proc. 2003;35(6):2176-8. Excluded because MPA not measured in blood. [pmid: 14529880].
Muller H, Solari S, Zuniga C, et al. Therapeutic drug monitoring of mycophenolic acid in kidney transplant patients: a abbreviated sampling strategy. Transplant Proc. 2007;39(3):596-9. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17445553].
Muller MM, Vogl M, Griesmacher A. Mycophenolic acid monitoring in HTX patients: a preliminary report. Therapie. 1997;52(4):341-4. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 9437889].
Munoz P, Fogeda M, Bouza E, et al. Prevalence of BK virus replication among recipients of solid organ transplants. Clin Infect Dis. 2005;41(12):1720-5. Excluded because MPA not measured in blood. [pmid: 16288394].
Naderer OJ, Dupuis RE, Heinzen EL, et al. The influence of norfloxacin and metronidazole on the disposition of mycophenolate mofetil. J Clin Pharmacol. 2005;45(2):219-26. Excluded because does not report on humans with a solid organ transplant. [pmid: 15647415].
Naesens M, Kuypers DRJ, Streit F, et al. Rifampin induces alterations in mycophenolic acid glucuronidation and elimination: Implications for drug exposure in renal allograft recipients. Clin Pharmacol Ther. 2006;80(5):509-21. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17112807].
Naesens M, Lerut E, Damme BV, et al. Tacrolimus exposure and evolution of renal allograft histology in the first year after transplantation. Am J Transplant. 2007;7(9):2114-23. Excluded because MPA not measured in blood. [pmid: 17608835].
Naesens M, De Loor H, Vanrenterghem Y, et al. The impact of renal allograft function on exposure and elimination of mycophenolic acid (MPA) and its metabolite MPA 7-O-glucuronide. Transplantation. 2007;84(3):362-73. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17700162].
Naesens M, De Loor H, Vanrenterghem Y, et al. The impact of renal allograft function on exposure and elimination of mycophenolic acid (MPA) and its metabolite MPA 7-O-glucuronide. Transplantation. 2007;84(3):362-73. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17700162].
Naesens M, Verbeke K, Vanrenterghem Y, et al. Effects of gastric emptying on oral mycophenolic acid pharmacokinetics in stable renal allograft recipients. Br J Clin Pharmacol. 2007;63(5):541-7. Excluded because not a full report of an included study type. [pmid: 17094777]. [pmcid: 2000747].
Nankivell BJ, Wavamunno MD, Borrows RJ, et al. Mycophenolate mofetil is associated with altered expression of chronic renal transplant histology. Am J Transplant. 2007;7(2):366-76. Excluded because MPA not measured in blood. [pmid: 17283486].
Nanni G, Pisanti F, Navarra P, et al. Lack of correlation between serum levels of mycophenolate mofetil and kidney transplant outcome in tacrolimus-based immunosupression. Transplant Proc. 2002;34(6):2085-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12270323].
Narumi S, Hakamada K, Sasaki M, et al. Liver transplantation for autoimmune hepatitis: Rejection and recurrence. Transplant Proc. 1999;31(5):1955-6. Excluded because MPA not measured in blood. [pmid: 10455934].
Neumann I, Haidinger M, Jager H, et al. Pharmacokinetics of mycophenolate mofetil in patients with autoimmune diseases compared renal transplant recipients. J Am Soc Nephrol. 2003;14(3):721-7. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12595508].
Ng KP, Cambridge G, Leandro MJ, et al. B cell depletion therapy in systemic lupus erythematosus: Long-term follow-up and predictors of response. Ann Rheum Dis. 2007;66(9):1259-62. Excluded because does not report on humans with a solid organ transplant. [pmid: 17412738].
Nobili V, Comparcola D, Sartorelli MR, et al. Mycophenolate mofetil in pediatric liver transplant patients with renal dysfunction: preliminary data.[erratum appears in Pediatr Transplant. 2004 Feb;8(1): 94]. Pediatr Transplant. 2003;7(6):454-7. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 14870893].
Nobili V, Comparcola D, Sartorelli MR, et al. Erratum: Mycophenolate mofetil in pediatric liver transplant patients with renal dysfunction: Preliminary data (Pediatric Transplantation (2003) 7 (454–457)). Pediatr Transplant. 2004;8(1):94. Excluded because not a full report of an included study type.
Nogueira E, Ozaki KS, Tomiyama H, et al. The emergence of cytomegalovirus resistance to ganciclovir therapy in kidney transplant recipients. Int Immunopharmacol. 2006;6(1314):2031-7. Excluded because MPA not measured in blood. [pmid: 17161359].
Nogueras F, Espinosa MD, Mansilla A, et al. Mycophenolate mofetil-induced neutropenia in liver transplantation. Transplant Proc. 2005;37(3):1509-11. Excluded because not a full report of an included study type. [pmid: 15866658].
Novoa P, Rodriguez L, Gutierrez L. Report of the experience with enteric-coated sodium mycophenolate in a de novo population of kidney transplant recipients at high risk for delayed graft function. Transplant Proc. 2007;39(3):600-1. Excluded because MPA not measured in blood. [pmid: 17445554].
Ogawa N, Nagashima N, Nakamura M, et al. Measurement of mycophenolate mofetil effect in transplant recipients. Transplantation. 2001;72(3):422-7. Excluded because MPA not measured in blood. [pmid: 11502970].
Okusanya O, Dole K, Zack J, et al. Population pharmacokinetic (PK) model of mycophenolic acid (MPA) and its metabolite - Mycophenolic acid glucoronide (MPAG) in long term transplant renal patients using Montecarlo parametric expectation maximization (MC-PEM). Clin Pharmacol Ther 2007;81(Suppl. 1): Excluded because not a full report of an included study type
Oliveira JG, Sampaio S, Xavier P, et al. Cytokine analysis before and after mycophenolate mofetil treatment in renal transplantation. Transplant Proc. 2000;32(8):2631-2. Excluded because MPA not measured in blood. [pmid: 11134732].
Ourahma S, Mercadal L, du Montcel ST, et al. Anemia in the Period Immediately Following Renal Transplantation. Transplant Proc. 2007;39(5):1446-50. Excluded because MPA not measured in blood. [pmid: 17580158].
Pageaux GP, Rostaing L, Calmus Y, et al. Mycophenolate mofetil in combination with reduction of calcineurin inhibitors for chronic renal dysfunction after liver transplantation. Liver Transpl. 2006;12(12):1755-60. Excluded because MPA not measured in blood. [pmid: 17133564].
Papadea CN, Weimert N, Uber W. Mycophenolic acid assay by tandem mass spectrometry: Analytical and clinical experience for immunosuppression in organ transplantation. Ann Clin Lab Sci 2007;37(2) Excluded because not a full report of an included study type
Pape L, Hoppe J, Becker T, et al. Superior long-term graft function and better growth of grafts in children receiving kidneys from paediatric compared with adult donors. Nephrol Dial Transplant. 2006;21(9):2596-600. Excluded because MPA not measured in blood. [pmid: 16861725].
Pape L, Ahlenstiel T, Ehrich JHH, et al. Reversal of loss of glomerular filtration rate in children with transplant nephropathy after switch to everolimus and low-dose cyclosporine A. Pediatr Transplant. 2007;11(3):291-5. Excluded because MPA not measured in blood. [pmid: 17430485].
Pareja-Ciuro F, Diez-Canedo JS, Gomez-Bravo MA, et al. Efficacy and safety of mycophenolate mofetil as part of induction therapy in liver transplantation. Transplant Proc. 2005;37(9):3926-9. Excluded because MPA not measured in blood. [pmid: 16386587].
Park SI, Felipe CR, Machado PG, et al. Pharmacokinetic/pharmacodynamic relationships of FTY720 in kidney transplant recipients. Braz J Med Biol Res. 2005;38(5):683-94. Excluded because MPA not measured in blood. [pmid: 15917949].
Pascual M, Curtis J, Delmonico FL, et al. A prospective, randomized clinical trial of cyclosporine reduction in stable patients greater than 12 months after renal transplantation. Transplantation. 2003;75(9):1501-5. Excluded because MPA not measured in blood. [pmid: 12792504].
Patel CG, Harmon M, Gohh RY, et al. Concentrations of mycophenolic acid and glucuronide metabolites under concomitant therapy with cyclosporine or tacrolimus. Ther Drug Monit. 2007;29(1):87-95. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17304155].
Patel J, Kawano M, Wu G, et al. Practically speaking: The initiation of lower dose mycophenolate mofetil (MMF)1000 mg bid appears to have similar outcome to 1500 mg bid after heart transplantation. J Heart Lung Transplant 2007;26(2, Suppl. S): Excluded because not a full report of an included study type
Pawinski T, Hale M, Korecka M, et al. Limited sampling strategy for the estimation of mycophenolic acid area under the curve in adult renal transplant patients treated with concomitant tacrolimus. Clin Chem. 2002;48(9):1497-504. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12194926].
Payen S, Zhang D, Maisin A, et al. Population pharmacokinetics of mycophenolic acid in kidney transplant pediatric and adolescent patients. Ther Drug Monit. 2005;27(3):378-88. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15905811].
Pelletier RP, Soule J, Henry ML, et al. Clinical outcomes of renal transplant recipients treated with enteric-coated mycophenolic acid vs. mycophenolate mofetil as a switch agent using a primary steroid-free rapamune and microemulsion cyclosporine protocol. Clin Transplant. 2007;21(4):532-5. Excluded because MPA not measured in blood. [pmid: 17645715].
Perkins JD. It matters to monitor drug levels. Liver Transpl. 2006;12(7):1169-70. Excluded because not a full report of an included study type. [pmid: 16874898].
Perrea DN, Moulakakis KG, Poulakou MV, et al. Correlation between oxidative stress and immunosuppressive therapy in renal transplant recipients with an uneventful postoperative course and stable renal function. Int Urol Nephrol. 2006;38(2):343-8. Excluded because MPA not measured in blood. [pmid: 16868708].
Perry TW, Christians U, Trotter JF, et al. Pharmacokinetics of enteric-coated mycophenolate sodium in stable liver transplant recipients. Clin Transplant. 2007;21(3):413-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17488394].
Pescovitz MD, Conti D, Dunn J, et al. Intravenous mycophenolate mofetil: safety, tolerability, and pharmacokinetics. Clin Transplant. 2000;14(3):179-88. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 10831074].
Pescovitz MD, Barbeito R, Simulect US. Two-hour post-dose cyclosporine level is a better predictor than trough level of acute rejection of renal allografts. Clin Transplant. 2002;16(5):378-82. Excluded because MPA not measured in blood. [pmid: 12225436].
Pescovitz MD, Guasch A, Gaston R, et al. Equivalent pharmacokinetics of mycophenolate mofetil in African-American and Caucasian male and female stable renal allograft recipients.[erratum appears in Am J Transplant. 2004 Nov;4(11):1928]. Am J Transplant. 2003;3(12):1581-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 14629290].
Pescovitz MD, Bumgardner G, Gaston RS, et al. Pharmacokinetics of daclizumab and mycophenolate mofetil with cyclosporine and steroids in renal transplantation. Clin Transplant. 2003;17(6):511-7. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 14756266].
Pethig K, Heublein B, Wahlers T, et al. Mycophenolate mofetil for secondary prevention of cardiac allograft vasculopathy: influence on inflammation and progression of intimal hyperplasia. J Heart Lung Transplant. 2004;23(1):61-6. Excluded because MPA not measured in blood. [pmid: 14734128].
Picard N, Cresteil T, Premaud A, et al. Characterization of a phase 1 metabolite of mycophenolic acid produced by CYP3A4/5. Ther Drug Monit. 2004;26(6):600-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15570183].
Picard N, Ratanasavanh D, Premaud A, et al. Identification of the UDP-glucuronosyltransferase isoforms involved in mycophenolic acid phase II metabolism. Drug Metab Dispos. 2005;33(1):139-46. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15470161].
Picard N, Premaud A, Rousseau A, et al. A comparison of the effect of ciclosporin and sirolimus on the pharmokinetics of mycophenolate in renal transplant patients. Br J Clin Pharmacol. 2006;62(4):477-84. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16995869]. [pmcid: 1885150].
Pieper AK, Buhle F, Bauer S, et al. The effect of sevelamer on the pharmacokinetics of cyclosporin A and mycophenolate mofetil after renal transplantation. Nephrol Dial Transplant. 2004;19(10):2630-3. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15304561].
Pietruck F, Budde K, Salvadori M, et al. Efficacy and safety of enteric-coated mycophenolate sodium in renal transplant patients with diabetes mellitus: post hoc analyses from three clinical trials. Clin Transplant. 2007;21(1):117-25. Excluded because MPA not measured in blood. [pmid: 17302600].
Pietruck F, Abbud-Filho M, Vathsala A, et al. Conversion from mycophenolate mofetil to enteric-coated mycophenolate sodium in stable maintenance renal transplant patients: pooled results from three international, multicenter studies. Transplant Proc. 2007;39(1):103-8. Excluded because MPA not measured in blood. [pmid: 17275484].
Pirsch J, Bekersky I, Vincenti F, et al. Coadministration of tacrolimus and mycophenolate mofetil in stable kidney transplant patients: pharmacokinetics and tolerability. J Clin Pharmacol. 2000;40(5):527-32. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 10806606].
Pisupati J, Jain A, Burckart G, et al. Intraindividual and interindividual variations in the pharmacokinetics of mycophenolic acid in liver transplant patients. J Clin Pharmacol. 2005;45(1):34-41. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15601803].
Pohanka E. Conversion to everolimus in maintenance patients—current clinical strategies. Nephrol Dial Transplant 2006;21:Suppl-9 Excluded because not a full report of an included study type
Pou L, Brunet M, Cantarell C, et al. Mycophenolic acid plasma concentrations: influence of comedication. Ther Drug Monit. 2001;23(1):35-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 11206040].
Pourfarziani V, Panahi Y, Assari S, et al. Changing Treatment Protocol From Azathioprine to Mycophenolate Mofetil: Decrease in Renal Dysfunction, Increase in Infections. Transplant Proc. 2007;39(4):1237-40. Excluded because MPA not measured in blood. [pmid: 17524943].
Premaud A, Rousseau A, Le Meur Y, et al. Comparison of liquid chromatography-tandem mass spectrometry with a commercial enzyme-multiplied immunoassay for the determination of plasma MPA in renal transplant recipients and consequences for therapeutic drug monitoring. Ther Drug Monit. 2004;26(6):609-19. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15570184].
Premaud A, Le Meur Y, Debord J, et al. Maximum a posteriori bayesian estimation of mycophenolic acid pharmacokinetics in renal transplant recipients at different postgrafting periods. Ther Drug Monit. 2005;27(3):354-61. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15905807].
Premaud A, Debord J, Rousseau A, et al. A double absorption-phase model adequately describes mycophenolic acid plasma profiles in de novo renal transplant recipients given oral mycophenolate mofetil. Clin Pharmacokinet. 2005;44(8):837-47. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16029068].
Premaud A, Rousseau A, Picard N, et al. Determination of mycophenolic acid plasma levels in renal transplant recipients co-administered sirolimus: comparison of an enzyme multiplied immunoassay technique (EMIT) and liquid chromatography-tandem mass spectrometry. Ther Drug Monit. 2006;28(2):274-7. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16628144].
Remuzzi G, Cravedi P, Costantini M, et al. Mycophenolate mofetil versus azathioprine for prevention of chronic allograft dysfunction in renal transplantation: The MYSS follow-up randomized, controlled clinical trial. J Am Soc Nephrol. 2007;18(6):1973-85. Excluded because MPA not measured in blood. [pmid: 17460145].
Remuzzi G, Perico N. Protecting single-kidney allografts from long-term functional deterioration. J Am Soc Nephrol. 1998;9(7):1321-32. Excluded because not a full report of an included study type. [pmid: 9644646].
Renders L, Steinbach R, Valerius T, et al. Low-dose sirolimus in combination with mycophenolate mofetil improves kidney graft function late after renal transplantation and suggests pharmacokinetic interaction of both immunosuppressive drugs. Kidney Blood Press Res. 2004;27(3):181-5. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15256815].
Rerolle JP, Szelag JC, Le Meur Y. Unexpected rate of severe leucopenia with the association of mycophenolate mofetil and valganciclovir in kidney transplant recipients. Nephrol Dial Transplant. 2007;22(2):671-2. Excluded because not a full report of an included study type. [pmid: 16980323].
Rial M, Guardia O, Greco G, et al. Area under the curve of Neoral and chronic use of mycophenolate mofetil. Yransplant Proc. 1998;30(4):1195-6. Excluded because MPA not measured in blood.
Riechsteiner G, Speich R, Schanz U, et al. Haemolytic anaemia after lung transplantation: an immune-mediated phenomenon?. Swiss Medical Weekly. 2003;133(910):143-7. Excluded because MPA not measured in blood. [pmid: 12707841].
Rigotti P. European Tacrolimus/MMF Transplantation Study Group. Patients with high cholesterol levels benefit most from early withdrawal of corticosteroids. Transplant Proc. 2002;34(5):1797-8. Excluded because MPA not measured in blood. [pmid: 12176581].
Rippin SJ, Serra AL, Marti HP, et al. Six-year follow-up of azathioprine and mycophenolate mofetil use during the first 6 months of renal transplantation. Clin Nephrol. 2007;67(6):374-80. Excluded because MPA not measured in blood. [pmid: 17598373].
Rose ML, Smith J, Dureau G, et al. Mycophenolate mofetil decreases antibody production after cardiac transplantation. J Heart Lung Transplant. 2002;21(2):282-5. Excluded because MPA not measured in blood. [pmid: 11834357].
Ruiz JC, Sanchez-Fructuoso A, Rodrigo E, et al. Conversion to Everolimus in Kidney Transplant Recipients: A Safe and Simple Procedure. Transplant Proc. 2006;38(8):2424-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17097956].
Saito K, Nakagawa Y, Suwa M, et al. Pinpoint targeted immunosuppression: anti-CD20/MMF desensitization with anti-CD25 in successful ABO-incompatible kidney transplantation without splenectomy. Xenotransplantation. 2006;13(2):111-7. Excluded because not a full report of an included study type. [pmid: 16623803].
Saliba F, Lakehal M, Pageaux GP, et al. Risk factors for new-onset diabetes mellitus following liver transplantation and impact of hepatitis C infection: An observational multicenter study. Liver Transpl. 2007;13(1):136-44. Excluded because MPA not measured in blood. [pmid: 17192854].
Sanchez FA, Calvo N, Moreno MA, et al. Better mycophenolic Acid 12-hour trough level after enteric-coated mycophenolate sodium in patients with gastrointestinal intolerance to mycophenolate mofetil. Transplant Proc. 2007;39(7):2194-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17889135].
Sanquer S, Breil M, Baron C, et al. Trough blood concentrations in long-term treatment with mycophenolate mofetil. Lancet. 1998;351(9115):1557. Excluded because not a full report of an included study type. [pmid: 10326544].
Sanquer S, Breil M, Baron C, et al. Induction of inosine monophosphate dehydrogenase activity after long-term treatment with mycophenolate mofetil. Clin Pharmacol Ther. 1999;65(6):640-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 10391669].
Schachter AD, Meyers KE, Spaneas LD, et al. Short sirolimus half-life in pediatric renal transplant recipients on a calcineurin inhibitor-free protocol. Pediatr Transplant. 2004;8(2):171-7. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15049798]. [pmcid: 1350260].
Schaefer HM, Kizilisik AT, Feurer I, et al. Short-term Results Under Three Different Immunosuppressive Regimens at One Center. Transplant Proc. 2006;38(10):3466-7. Excluded because MPA not measured in blood. [pmid: 17175305].
Schlavelli R, Gaite L, Carreno C, et al. Use of enteric-coated mycophenolate sodium in de novo renal transplant recipients with high incidence of delayed graft function. Transplant Proc. 2006;38(5):905. Excluded because MPA not measured in blood. [pmid: 16647505].
Schlitt HJ, Barkmann A, Boker KH, et al. Replacement of calcineurin inhibitors with mycophenolate mofetil in liver-transplant patients with renal dysfunction: a randomised controlled study. Lancet. 2001;357(9256):587-91. Excluded because MPA not measured in blood. [pmid: 11558484].
Schmidt LE, Rasmussen A, Norrelykke MR, et al. The effect of selective bowel decontamination on the pharmacokinetics of mycophenolate mofetil in liver transplant recipients. Liver Transpl. 2001;7(8):739-42. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 11510021].
Schutz E, Armstrong VW, Shipkova M, et al. Limited sampling strategy for the determination of mycophenolic acid area under the curve in pediatric kidney recipients. German Study Group on MMF Therapy in Pediatric Renal Transplant Recipients. Transplant Proc. 1998;30(4):1182-4. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 9636478].
Schutz E, Shipkova M, Armstrong VW, et al. Therapeutic drug monitoring of mycophenolic acid: comparison of HPLC and immunoassay reveals new MPA metabolites. Transplant Proc. 1998;30(4):1185-7. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 9636479].
Schutz E, Shipkova M, Armstrong VW, et al. Identification of a pharmacologically active metabolite of mycophenolic acid in plasma of transplant recipients treated with mycophenolate mofetil. Clin Chem. 1999;45(3):419-22. Excluded because not a full report of an included study type. [pmid: 10053049].
Schweiger M, Wasler A, Prenner G, et al. Everolimus and reduced cyclosporine trough levels in maintenance heart transplant recipients. Transpl Immunol. 2006;16(1):46-51. Excluded because MPA not measured in blood. [pmid: 16701176].
Schweitzer EJ, Yoon S, Fink J, et al. Mycophenolate mofetil reduces the risk of acute rejection less in African-American than in Caucasian kidney recipients. Transplantation. 1998;65(2):242-8. Excluded because MPA not measured in blood. [pmid: 9458022].
Seebacher G, Mallinger R, Laufer G, et al. Pharmacokinetics of mycophenolate mofetil in heart transplant recipients. Adv Exp Med Biol. 1998;431:801-3. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 9598174].
Seipelt IM, Crawford SE, Rodgers S, et al. Hypercholesterolemia is common after pediatric heart transplantation: initial experience with pravastatin. J Heart Lung Transplant. 2004;23(3):317-22. Excluded because MPA not measured in blood. [pmid: 15019641].
Seron D. Is halving ciclosporin dose and introducing mycophenolate beneficial in chronic renal allograft dysfunction?. Nat Clin Pract Nephrol. 2007;3(4):198-9. Excluded because not a full report of an included study type. [pmid: 17310227].
Shaw LM. Mycophenolate mofetil: pharmacokinetic strategies for optimizing immunosuppression. Drug Metabol Drug Interact. 1997;14(1):33-40. Excluded because not a full report of an included study type. [pmid: 9713576].
Sheashaa HA, Bakr MA, Fouda MA, et al. Is it worth using daclizumab induction therapy with mycophenolate mofetil-based immunosuppressive regimens in live related donor kidney transplantation? A long-term follow up. Int Urol Nephrol. 2007;39(1):317-9. Excluded because MPA not measured in blood. [pmid: 17333530].
Shi Y, Moriyama T, Namba Y, et al. Association of treatment with 15-deoxyspergualin and BK virus nephropathy in kidney allograft recipients. Clin Transplant. 2007;21(4):502-9. Excluded because MPA not measured in blood. [pmid: 17645710].
Shipkova M, Armstrong VW, Schneider T, et al. Stability of mycophenolic acid and mycophenolic acid glucuronide in human plasma. Clin Chem. 1999;45(1):127-9. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 9895349].
Shipkova M, Armstrong VW, Kuypers D, et al. Effect of cyclosporine withdrawal on mycophenolic acid pharmacokinetics in kidney transplant recipients with deteriorating renal function: preliminary report. Ther Drug Monit. 2001;23(6):717-21. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 11802109].
Shipkova M, Armstrong VW, Kiehl MG, et al. Quantification of mycophenolic acid in plasma samples collected during and immediately after intravenous administration of mycophenolate mofetil. Clin Chem. 2001;47(8):1485-8. Excluded because not a full report of an included study type. [pmid: 11468247].
Shipkova M, Armstrong VW, Weber L, et al. Pharmacokinetics and protein adduct formation of the pharmacologically active acyl glucuronide metabolite of mycophenolic acid in pediatric renal transplant recipients. Ther Drug Monit. 2002;24(3):390-9. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12021631].
Shiroki R, Hoshinaga K, Higuchi T, et al. Analysis of the effects of recipient age and pretransplant hemodialysis period on cadaveric kidney transplant outcome using non-heart-beating donors. Transplant Proc. 1999;31(5):1970-2. Excluded because MPA not measured in blood. [pmid: 10455939].
Shum B, Duffull SB, Taylor PJ, et al. Population pharmacokinetic analysis of mycophenolic acid in renal transplant recipients following oral administration of mycophenolate mofetil. Br J Clin Pharmacol. 2003;56(2):188-97. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12895192]. [pmcid: 1884287].
Sievers TM, Holt CD, Ghobrial RM, et al. Pharmacokinetics of mycophenolic acid and clinical outcomes in liver transplant recepients with hepatitis C (HCV). Am J Transplant 2004;4(Suppl 8):365, 2004. Excluded because not a full report of an included study type
Silva LA, Felipe CR, Park SI, et al. Impact of initial exposure to calcineurin inhibitors on kidney graft function of patients at high risk to develop delayed graft function. Braz J Med Biol Res. 2006;39(1):43-52. Excluded because MPA not measured in blood. [pmid: 16400463].
Sindhi R, Magill A, Manavalan S, et al. Peripheral lymphocyte markers as surrogate measures of immunosuppression and post-transplant clinical states. Clinical & Applied Immunology Reviews. 2004;4(4):225-38. Excluded because not a full report of an included study type.
Smak Gregoor PJ, van Gelder T, Hesse CJ, et al. Mycophenolic acid plasma concentrations in kidney allograft recipients with or without cyclosporin: a cross-sectional study. Nephrol Dial Transplant. 1999;14(3):706-8. Excluded because not a full report of an included study type. [pmid: 10193823].
Squifflet JP, Vanrenterghem Y, Van Hooff JP, et al. Safe withdrawal of corticosteroids or mycophenolate mofetil: results of a large, prospective, multicenter, randomized study. Transplant Proc. 2002;34(5):1584-6. Excluded because MPA not measured in blood. [pmid: 12176495].
Srinivas TR, Schold JD, Guerra G, et al. Mycophenolate mofetil/sirolimus compared to other common immunosuppressive regimens in kidney transplantation. Am J Transplant. 2007;7(3):586-94. Excluded because MPA not measured in blood. [pmid: 17229066].
Staatz CE, Duffull SB, Kiberd B, et al. Population pharmacokinetics of mycophenolic acid during the first week after renal transplantation. Eur J Clin Pharmacol. 2005;61(7):507-16. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16049701].
Stalder M, Birsan T, Holm B, et al. Quantification of immunosuppression by flow cytometry in stable renal transplant recipients. Ther Drug Monit. 2003;25(1):22-7. Excluded because MPA not measured in blood. [pmid: 12548140].
Stratta RJ, Sundberg AK, Farney AC, et al. Experience with alternate-day thymoglobulin induction in pancreas transplantation with portal-enteric drainage. Transplant Proc. 2005;37(8):3546-8. Excluded because MPA not measured in blood. [pmid: 16298656].
Subbanna PK, Prasanna CG, Gunale BK. Investigation on pharmacokinetics of mycophenolic acid in Chinese adult renal transplant patients [1]. Br J Clin Pharmacol. 2007;64(2):245. Excluded because not a full report of an included study type. [pmid: 17425626]. [pmcid: 2000630].
Sudchada P, Dole K, Zack J, et al. Influence of race and steroid use on mycophenolic acid pharmacokinetics post-renaltransplant. Clin Pharmacol Ther 2007;81(Suppl. 1): Excluded because not a full report of an included study type
Sumethkul V, Changsirikulchai S, Lothuvachai T, et al. Sirolimus Attenuates the Rate of Progression of Early Chronic Allograft Nephropathy. Transplant Proc. 2006;38(10):3470-2. Excluded because MPA not measured in blood. [pmid: 17175307].
Sun Q, Liu ZH, Chen J, et al. An aggressive systematic strategy for acute respiratory distress syndrome caused by severe pneumonia after renal transplantation. Transpl Int. 2006;19(2):110-6. Excluded because MPA not measured in blood. [pmid: 16441359].
Sun Q, Liu ZH, Cheng Z, et al. Treatment of early mixed cellular and humoral renal allograft rejection with tacrolimus and mycophenolate mofetil. Kidney Int. 2007;71(1):24-30. Excluded because MPA not measured in blood. [pmid: 16969384].
Suntornsuk L, Meyer T, Lindgren A, et al. A micellar electrokinetic capillary chromatography method for monitoring mycophenolic acid in serum of transplant recipients. Pharmazie. 2005;60(2):115-9. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15739899].
Suwelack B, Gerhardt U, Kobelt V, et al. Design and preliminary results of a randomized study on the conversion of treatment with calcineurin inhibitors to mycophenolate mofetil in chronic renal graft failure: effect, on serum cholesterol levels. Transplant Proc. 2002;34(5):1803-5. Excluded because MPA not measured in blood. [pmid: 12176583].
Suwelack B, Kobelt V, Hillebrand U, et al. Replacement of calcineurin inhibitors by mycophenolate mofetil: effect on hemoglobine levels. Transplant Proc. 2002;34(5):1808-9. Excluded because MPA not measured in blood. [pmid: 12176585].
Szwarc I, Argiles A, Garrigue V, et al. Cinacalcet chloride is efficient and safe in renal transplant recipients with posttransplant hyperparathyroidism. Transplantation. 2006;82(5):675-80. Excluded because MPA not measured in blood. [pmid: 16969292].
Takami A, Mochizuki K, Okumura H, et al. Mycophenolate mofetil is effective and well tolerated in the treatment of refractory acute and chronic graft-versus-host disease. Int J Hematol. 2006;83(1):80-5. Excluded because does not report on humans with a solid organ transplant. [pmid: 16443558].
Takekuma Y, Kakiuchi H, Yamazaki K, et al. Difference between pharmacokinetics of mycophenolic acid (MPA) in rats and that in humans is caused by different affinities of MRP2 to a glucuronized form. J Pharm Pharm Sci. 2007;10(1):71-85. Excluded because does not report on humans with a solid organ transplant. [pmid: 17498396].
Tamajon LP, Miranda DM, Figueroa AC, et al. Improved cardiovascular risk profile of patients with type 1 diabetes mellitus and renal failure after simultaneous pancreas-kidney transplantation. Transplant Proc. 2005;37(9):3979-80. Excluded because MPA not measured in blood. [pmid: 16386603].
Tannuri U, Gibelli NEM, Maksoud-Filho JG, et al. Mycophenolate mofetil promotes prolonged improvement of renal dysfunction after pediatric liver transplantation: Experience of a single center. Pediatr Transplant. 2007;11(1):82-6. Excluded because MPA not measured in blood. [pmid: 17239128].
Tedesco-Silva H, Mourad G, Kahan BD, et al. FTY720, a novel immunomodulator: efficacy and safety results from the first phase 2A study in de novo renal transplantation. [republished in Transplantation. 2005 Jun 15;79(11):1553–60; PMID: 15940045]. Transplantation. 2004;77(12):1826-33. Excluded because MPA not measured in blood. [pmid: 15223899].
Tedesco-Silva H, Bastien MC, Choi L, et al. Mycophenolic acid metabolite profile in renal transplant patients receiving enteric-coated mycophenolate sodium or mycophenolate mofetil. Transplant Proc. 2005;37(2):852-5. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15848554].
Tedesco-Silva H, Pescovitz MD, Cibrik D, et al. Randomized controlled trial of FTY720 versus MMF in de novo renal transplantation. Transplantation. 2006;82(12):1689-97. Excluded because MPA not measured in blood. [pmid: 17198261].
Tedoriya T, Keogh AM, Kusano K, et al. Reversal of chronic cyclosporine nephrotoxicity after heart transplantation-potential role of mycophenolate mofetil. J Heart Lung Transplant. 2002;21(9):976-82. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 12231368].
Teebken OE, Struber M, Harringer W, et al. Primary immunosuppression with tacrolimus and mycophenolate mofetil versus cyclosporine and azathioprine in heart transplant recipients. Transplant Proc. 2002;34(4):1265-8. Excluded because MPA not measured in blood. [pmid: 12072335].
Ting LS, Partovi N, Levy RD, et al. Pharmacokinetics of mycophenolic acid and its glucuronidated metabolites in stable lung transplant recipients. Ann Pharmacother. 2006;40(9):1509-16. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16882870].
Ting LS, Decarie D, Ensom MH. Effect of acidification on protein binding of mycophenolic acid. Ther Drug Monit. 2007;29(1):132-3. Excluded because not a full report of an included study type. [pmid: 17304164].
Ting LSL, Partovi N, Levy RD, et al. Limited sampling strategy for predicting area under the concentration-time curve of mycophenolic acid in adult lung transplant recipients. Pharmacotherapy. 2006;26(9 I):1232-40. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16945044].
Tripodi V, Nunez M, Carducci C, et al. Total serum bile acids in renal transplanted patients receiving cyclosporine A. Clin Nephrol. 2002;58(5):350-5. Excluded because MPA not measured in blood. [pmid: 12425485].
Trivedi H, Vanikar AV, Modi P, et al. Allogeneic hematopoietic stem-cell transplantation mixed chimerism, and tolerance in living related donor renal allograft recipients. Transplant Proc. 2005;37(2):737-42. Excluded because MPA not measured in blood. [pmid: 15848518].
Tsai MK, Lee CY, Hu RH, et al. Conversion to combined therapy with sirolimus and mycophenolate mofetil improved renal function in stable renal transplant recipients. J Formos Med Assoc. 2007;106(5):372-9. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17561472].
Undre NA, van Hooff J, Christiaans M, et al. Pharmacokinetics of FK 506 and mycophenolic acid after the administration of a FK 506-based regimen in combination with mycophenolate mofetil in kidney transplantation. Transplant Proc. 1998;30(4):1299-302. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 9636527].
Unsalan S, Hempel G, Fobker M, et al. Monitoring of mycophenolic acid in the plasma of transplant patients by capillary electrophoresis. Chromatographia. 2006;64(78):419-21. Excluded because MPA levels not associated with any clinical outcomes.
Uwai Y, Motohashi H, Tsuji Y, et al. Interaction and transport characteristics of mycophenolic acid and its glucuronide via human organic anion transporters hOAT1 and hOAT3. Biochem Pharmacol. 2007;74(1):161-8. Excluded because does not report on humans with a solid organ transplant. [pmid: 17462604].
van Besouw NM, Van Der Mast BJ, de Kuiper P, et al. Down-regulated donor-specific T-cell reactivity during successful tapering of immunosuppression after kidney transplantation. Clin Exp Immunol. 2002;128(2):388-93. Excluded because MPA not measured in blood. [pmid: 11985532]. [pmcid: 1906400].
Van Der Mast BJ, van Besouw NM, Witvliet MD, et al. Formation of donor-specific human leukocyte antigen antibodies after kidney transplantation: correlation with acute rejection and tapering of immunosuppression. Transplantation. 2003;75(6):871-7. Excluded because MPA not measured in blood. [pmid: 12660517].
Van Hest R, Mathot R, Vulto A, et al. Predicting the usefulness of therapeutic drug monitoring of mycophenolic acid: a computer simulation. Ther Drug Monit. 2005;27(2):163-7. Excluded because not a full report of an included study type. [pmid: 15795646].
Van Hest RM, Mathot RA, Vulto AG, et al. Mycophenolic acid in diabetic renal transplant recipients: pharmacokinetics and application of a limited sampling strategy. Ther Drug Monit. 2004;26(6):620-5. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15570185].
Van Hest RM, van Gelder T, Vulto AG, et al. Population pharmacokinetics of mycophenolic acid in renal transplant recipients. Clin Pharmacokinet. 2005;44(10):1083-96. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16176120].
van Hest RM, van Gelder T, Bouw R, et al. Time-dependent clearance of mycophenolic acid in renal transplant recipients. Br J Clin Pharmacol. 2007;63(6):741-52. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17214827]. [pmcid: 2000600].
van Hest RM, Doorduijn JK, de Winter BC, et al. Pharmacokinetics of mycophenolate mofetil in hematopoietic stem cell transplant recipients. Ther Drug Monit. 2007;29(3):353-60. Excluded because does not report on humans with a solid organ transplant. [pmid: 17529894].
Vannozzi F, Filipponi F, Di Paolo A, et al. An exploratory study on pharmacogenetics of inosine-monophosphate dehydrogenase II in peripheral mononuclear cells from liver-transplant recipients. Transplant Proc. 2004;36(9):2787-90. Excluded because MPA not measured in blood. [pmid: 15621150].
Velthuis JHL, Mol WM, Weimar W, et al. CD4<sup>+</sup> CD25<sup>bright+</sup> regulatory T cells can mediate donor nonreactivity in long-term immunosuppressed kidney allograft patients. Am J Transplant. 2006;6(12):2955-64. Excluded because MPA not measured in blood. [pmid: 17294523].
Vessal G, Wiland AM, Philosophe B, et al. Early steroid withdrawal in solitary pancreas transplantation results in equivalent graft and patient survival compared with maintenance steroid therapy. Clin Transplant. 2007;21(4):491-7. Excluded because MPA not measured in blood. [pmid: 17645708].
Vethe NT, Mandla R, Line PD, et al. Inosine monophosphate dehydrogenase activity in renal allograft recipients during mycophenolate treatment. Scan J Clin Lab Invest. 2006;66(1):31-44. Excluded because MPA levels not associated with any clinical outcomes.
Vidal E, Cantarell C, Capdevila L, et al. Mycophenolate mofetil pharmacokinetics in transplant patients receiving cyclosporine or tacrolimus in combination therapy. Pharmacology and Toxicology. 2000;87(4):182-4. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 11097273].
Videla C, Godoy C. Converting to a generic formulation of mycophenolate mofetil in stable kidney transplant recipients: 1 year of drug surveillance and outcome. Transplant Proc. 2007;39(3):602-5. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17445555].
Vietri M, Pietrabissa A, Mosca F, et al. Inhibition of mycophenolic acid glucuronidation by niflumic acid in human liver microsomes. Eur J Clin Pharmacol. 2002;58(2):93-7. Excluded because does not report on humans with a solid organ transplant. [pmid: 12012139].
Wada K, Takada M, Ueda T, et al. Pharmacokinetic study and limited sampling strategy of cyclosporine in Japanese heart transplant recipients. Circ J. 2006;70(10):1307-11. Excluded because MPA not measured in blood. [pmid: 16998264].
Wada K, Takada M, Ueda T, et al. Relationship between acute rejection and cyclosporine or mycophenolic acid levels in Japanese heart transplantation. Circ J. 2007;71(3):289-93. Excluded because not a full report of an included study type. [pmid: 17322623].
Wada K, Takada M, Kotake T, et al. Limited sampling strategy for mycophenolic acid in Japanese heart transplant recipients: comparison of cyclosporin and tacrolimus treatment. Circ J. 2007;71(7):1022-8. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17587705].
Wada K, Kato T, Oda N, et al. Therapeutic monitoring of mycophenolate mofetile dose by twelve-hour-area under the curve to avoid acute rejection in heart transplant recipients. J Heart Lung Transplant 2007;26(2, Suppl. S): Excluded because not a full report of an included study type
Wang J, Zeevi A, Webber S, et al. IMPDH2 and mycophenolic acid: Effect of a novel SNP on enzyme activity and leukopenia in transplant patients. J Clin Pharmacol 2006;46(9): Excluded because not a full report of an included study type
Wang W. A pilot trial with pig-to-man islet transplantation at the 3rd Xiang-Ya Hospital of the Central South University in Changsha. Xenotransplantation. 2007;14(4):358. Excluded because MPA not measured in blood.
Wang XH, Tang XD, Xu D. Tacrolimus vs CyA Neoral in combination with MMF and steroids after cadaveric renal transplantation. Transplant Proc. 2000;32(7):1702-3. Excluded because MPA not measured in blood. [pmid: 11119899].
Wawrzynowicz-Syczewska M, Herman E, Jurczyk K, et al. Does cyclosporine inhibit in vivo hepatitis C virus replication? - A pilot study [1]. Transpl Int. 2007;20(9):808-10. Excluded because MPA not measured in blood. [pmid: 17578456].
Weber LT, Schutz E, Lamersdorf T, et al. Pharmacokinetics of mycophenolic acid (MPA) and free MPA in paediatric renal transplant recipients - A multicentre study. Nephrol Dial Transplant. 1999;14(SUPPL.4):33-4. Excluded because not a full report of an included study type.
Weber LT, Schutz E, Lamersdorf T, et al. Therapeutic drug monitoring of total and free mycophenolic acid (MPA) and limited sampling strategy for determination of MPA-AUC in paediatric renal transplant recipients. Nephrol Dials Transplant. 1999;14(SUPPL. 4):34-5. Excluded because MPA levels not associated with any clinical outcomes.
Weigel G, Griesmacher A, Zuckermann AO, et al. Effect of mycophenolate mofetil therapy on inosine monophosphate dehydrogenase induction in red blood cells of heart transplant recipients. Clin Pharmacol Ther. 2001;69(3):137-44. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 11240978].
Weigel G, Griesmacher A, Karimi A, et al. Effect of mycophenolate mofetil therapy on lymphocyte activation in heart transplant recipients. J Heart Lung Transplant. 2002;21(10):1074-9. Excluded because MPA not measured in blood. [pmid: 12398872].
Weimer R, Streller S, Staak A, et al. Effects of three immunosuppressive regimens on CD4 helper function, B cell monocyte and cytokine responses in renal transplant recipients: 4-month follow-up of a prospective randomized study. Transplant Proc. 2002;34(6):2377-8. Excluded because MPA not measured in blood. [pmid: 12270445].
Weimer R, Mytilineos J, Feustel A, et al. Mycophenolate mofetil-based immunosuppression and cytokine genotypes: effects on monokine secretion and antigen presentation in long-term renal transplant recipients. Transplantation. 2003;75(12):2090-9. Excluded because MPA not measured in blood. [pmid: 12829918].
Weimer R, Susal C, Yildiz S, et al. sCD30 and neopterin as risk factors of chronic renal transplant rejection: impact of cyclosporine A, tacrolimus, and mycophenolate mofetil. Transplant Proc. 2005;37(4):1776-8. Excluded because MPA not measured in blood. [pmid: 15919463].
Westley IS, Ray JE, Morris RG. CEDIA mycophenolic acid assay compared with HPLC-UV in specimens from transplant recipients. Ther Drug Monit. 2006;28(5):632-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17038877].
Wierzbicka A, Pawlowska J, Socha P, et al. Lipid, Carbohydrate Metabolism, and Antioxidant Status in Children After Liver Transplantation. Transplant Proc. 2007;39(5):1523-5. Excluded because MPA not measured in blood. [pmid: 17580179].
Wiesner RH, Steffen BJ, David KM, et al. Mycophenolate mofetil use is associated with decreased risk of late acute rejection in adult liver transplant recipients. Am J Transplant. 2006;6(7):1609-16. Excluded because MPA not measured in blood. [pmid: 16827861].
Wigger M, Armstrong VW, Shipkova M, et al. Atypical pharmacokinetics and metabolism of mycophenolic acid in a young kidney transplant recipient with impaired renal function. Ther Drug Monit. 2002;24(3):438-43. Excluded because not a full report of an included study type. [pmid: 12021639].
Winkelmayer WC, Kewalramani R, Rutstein M, et al. Pharmacoepidemiology of anemia in kidney transplant recipients. J Am Soc Nephrol. 2004;15(5):1347-52. Excluded because MPA not measured in blood. [pmid: 15100376].
Wlodarczyk Z, Walaszewski J, Perner F, et al. Freedom from rejection and stable kidney function are excellent criteria for steroid withdrawal in tacrolimus-treated kidney transplant recipients. Ann Transplant. 2002;7(3):28-31. Excluded because MPA not measured in blood.
Wong BM, Huang M, Zaltzman JS, et al. Mycophenolate mofetil and c-reactive protein in renal transplant recipients. Transplantation. 2007;83(1):48-53. Excluded because MPA not measured in blood. [pmid: 17220790].
Xia D, Yan LN, Xu L, et al. Postoperative Severe Pneumonia in Adult Liver Transplant Recipients. Transplant Proc. 2006;38(9):2974-8. Excluded because MPA not measured in blood. [pmid: 17112878].
Yeung S, Tong KL, Tsang WK, et al. Pharmacokinetic study of mycophenolate mofetil in Asian renal transplant recipients. Transplant Proc. 2000;32(7):1753-4. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 11119920].
Yeung S, Tsang WK, Tong KL, et al. Primary immunosuppression with tacrolimus and low-dose mycophenolate mofetil in renal transplant recipients. Transplant Proc. 2004;36(7):2084-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 15518754].
Yin J, Wang S, Yang G, et al. Molecularly imprinted solid-phase extraction for rapid screening of mycophenolic acid in human plasma. J Chromatogr B. 2006;844(1):142-7. Excluded because does not report on humans with a solid organ transplant.
Ying C, Colonno R, De Clercq E, et al. Ribavirin and mycophenolic acid markedly potentiate the anti-hepatitis B virus activity of entecavir. Antiviral Res. 2007;73(3):192-6. Excluded because does not report on humans with a solid organ transplant. [pmid: 17098296].
Yorgin PD, Scandling JD, Belson A, et al. Late post-transplant anemia in adult renal transplant recipients. An under-recognized problem?. Am J Transplant. 2002;2(5):429-35. Excluded because MPA not measured in blood. [pmid: 12123208].
Yu L, Wang Y, Fu SJ, et al. Clinical experience with Prograf (tacrolimus, FK 506) in Chinese patients after renal transplantation. Transplant Proc. 2000;32(7):1709-10. Excluded because MPA not measured in blood. [pmid: 11119902].
Zanker B, Sohr B, Eder M, et al. Comparison of MPA trough levels in patients with severe diabetes mellitus and from non-diabetics after transplantation. Transplant Proc 31(1–2):1167. Excluded because MPA levels not associated with any clinical outcomes
Zanker B, Schleibner S, Schneeberger H, et al. Mycophenolate mofetil in patients with acute renal failure: evidence of metabolite (MPAG) accumulation and removal by dialysis. Transpl Int 1996;9:Suppl-10 Excluded because MPA levels not associated with any clinical outcomes
Zhou PJ, Xu D, Yu ZC, et al. Pharmacokinetics of mycophenolic acid and estimation of exposure using multiple linear regression equations in Chinese renal allograft recipients. Clin Pharmacokinet. 2007;46(5):389-401. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17465638].
Zicheng Y, Peijun Z, Da X, et al. Investigation on pharmacokinetics of mycophenolic acid in Chinese adult renal transplant patients. Br J Clin Pharmacol. 2006;62(4):446-52. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 16995865]. [pmcid: 1885158].
Zicheng Y, Weixia Z, Hao C, et al. Limited sampling strategy for the estimation of mycophenolic acid area under the plasma concentration-time curve in adult patients undergoing liver transplant. Ther Drug Monit. 2007;29(2):207-14. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17417076].
Zicheng Y, Xianghui W, Peijun Z, et al. Evaluation of the practicability of limited sampling strategies for the estimation of mycophenolic acid exposure in Chinese adult renal recipients. Ther Drug Monit. 2007;29(5):600-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 17898650].
Zucker K, Rosen A, Tsaroucha A, et al. Augmentation of mycophenolate mofetil pharmacokinetics in renal transplant patients receiving Prograf and CellCept in combination therapy. Transplant Proc. 1997;29(12):334-6. Excluded because MPA levels not associated with any clinical outcomes. [pmid: 9123027].