# Appendix C. Evidence Tables

Evidence Table 1. General information for all included studies

Study ID | Study Description | Population | Treatment | Measures | Outcomes
Author: Armstrong | Aim: Compare the clinical utility of the EMIT assay with HPLC for discriminating acute rejection in pediatric renal transplant recipients | Population: Pediatric renal tx; 9 patients: ≥ 1 acute rejection episode | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2001 | Comparison of monitored patients with others: No | 31 patients: no rejection episode | Dose: 600 mg/m^2^ BID | Method of measurement: C_0_, AUC_(0–12h)_, C_max_ | Length of followup: 70d
Country: Germany | Study design: Case series | Organ transplanted: Kidney (Renal) | Prospective dose adjustment planned: No | Frequency of MPA measure: day 7, day 21
| Entered into study: 40 | Age: Inclusion requirement pediatric | Concomitant medications: Cyclosporine | Assay used: HPLC
| Analyzed: 40 | Mean NR | Methylpred. | EMIT
| | % Male: NR | Prednisone
| | Weight: NR
Author: Atcheson | Aim: To investigate PK of MPA | Population: Caucasian 98% | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2004 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1g BID | fMPA | GI
Country: Australia | Study design: Prospective Cohort | Age: Mean 44.3 +/- 13.1y | Prospective dose adjustment planned: No | Method of measurement: AUC_(0–6h)_ C_0_ | anemia
| Entered into study: 42 | % Male: 57 | Concomitant medications: Cyclosporine n=32 | Frequency of MPA measure: day 5 after transplantation | thrombocytopenia
| Analyzed: 42 | Weight: Mean 72.9 +/- 14.8 kg | Tacrolimus n=10 | Assay used: HPLC UV and MS-MS | leucopenia
| | BMI 25.3 +/- 3.9 kg/m^2^ | Simulect | | Length of followup: 1m
| | | Diltiazem
| | | Prednisolone
Author: Barbari | Aim: To determine MPA trough level correlation with outcomes | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2005b | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1 g 2 times a day range 1 – 2.5 g/day | Method of measurement: C_0_ | lymphocyte count
Country: Lebanon | Study design: Case control | Age: Mean 39y | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels | Frequency of MPA measure: NR | Length of followup: NR
| Entered into study: 30 | Range 20–67y | Concomitant medications: Cyclosporine | Assay used: monoclonal antibody based ELISA kit
| Analyzed: NR | % Male: 63.3 | Prednisone
| | Weight: NR
Author: Barbari | Aim: To assess realtionship between clinical outcome, lymphocyte count and cyclosporine lymphocyte max level | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: NR | Health outcome: acute rejection
Year: 2005a | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 2 g/day | Method of measurement: NR | Length of followup: NR
Country: Lebanon | Study design: Case control | Age: NR | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels | Frequency of MPA measure: NR
| Entered into study: Condition 1, graft dysfunctions: 12 | % Male: NR | Concomitant medications: Cyclosporine | Assay used: NR
| Condition 2, no events: 23 | Weight: NR | Prednisone
| Analyzed: NR
Author: Behrend | Aim: MPA and MPAG trough levels after renal transplantation | Population: followup to a previously reported RCT; | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: graft function
Year: 1997 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 2 g/day or 3 g/day; dose per body weight was 22 to 54 mg/kg; mean 83 mg/kg ± 8.4 body weight | MPAG | adverse events
Country: Germany | Study design: RCT | Age: NR | Prospective dose adjustment planned: No | Method of measurement: trough levels | infections
| Entered into study: 57 | % Male: NR | Concomitant medications: Cyclosporine | Frequency of MPA measure: samples from patients varied from 4–32 | acute rejection
| Analyzed: 48 | Weight: NR | Corticosteroids | Assay used: HPLC | Length of followup: ≥1y
Author: Bilbao | Aim: Immunosuppression based on MMF in stable liver transplanted patients. | Population: Stable liver transplant patients | Form given: Mycophenolate mofetil (MMF, CellCept) MMF | Form measured: MMF only mentioned but meant MPA | Health outcome: acute transplant rejection
Year: 2006 | Comparison of monitored patients with others: No | Organ transplanted: Liver | Dose: Initial dose of 500 mg/12h; reaching dose of 1 g each 12h for 2 weeks. | Method of measurement: trough levels | death
Country: Spain | Study design: Case series | Age: Mean 59 +/ - 6y | Prospective dose adjustment planned: Yes - based on clinical indicators adjusted to tolerability and side effects | Frequency of MPA measure: Every 3 months for the first year, every 6 months until the 4th year then yearly until year 6. | progression of renal dysfunction
| Entered into study: 56 | % Male: 61% | Concomitant medications: Cyclosporine | Assay used: NR | progression of HCV recurrence
| Analyzed: 56 | Weight: NR | Tacrolimus | | mild diarrhea
| | | | | leucopenia
| | | | | de novo tumour
| | | | | Length of followup: mean 39 ± 20m; range 3 to 72m.
Author: Borrows | Aim: TDM of MPA associations with toxicity and rejections | Population: | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2006 | Comparison of monitored patients with others: No | Caucasian 55% | Dose: 750 mg BID | Method of measurement: trough levels | white blod cell count
Country: UK | Study design: Case series | South Asian 23% | Prospective dose adjustment planned: Yes - based on clinical indicators only | Frequency of MPA measure: day 7, month 1, 3, 6, 12 | leucopenia
| Entered into study: 121 | Afro-Carib 18% | Concomitant medications: Tacrolimus | Assay used: EMIT | thrombocytopenia
| Analyzed: 121 | Other 4% | Methylpred. | | bacteria/viral infection
| | Organ transplanted: Kidney (Renal) | Prednisone | | heamoglobin/anemia
| | Age: Mean 46 +/- 9y | Corticosteroids | | Length of followup: minimum of 12m
| | Range 37–55y | Ganciclovir (for 3m) | | median 25m
| | % Male: 58 | Co-trimoxazole (for 6m) | | range 13–38m
| | Weight: NR | Isoniazid and pyridoxine (in Indo-Asians and previous TB)
| | | Basiliximab or Daclizumab (in 79 patients)
Author: Borrows | Aim: To understand the determinants of MPA levels and thus aid TDM of MMF | Population: | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: diarrhea
Year: 2005 | Comparison of monitored patients with others: No | White 55.6% | Dose: 250–3000 mg/day | Method of measurement: C_0_ | Length of followup: 30 m median
Country: UK | Study design: Case series | Indo-Asian 23.1 | Prospective dose adjustment planned: Yes - based on clinical indicators | Frequency of MPA measure: week 1, 2, 3, 4, month 2–3, 4–6, 7–12, >12 | 19m
| Entered into study: 117 | Afro-Carib 17.9% | Concomitant medications: Tacrolimus | Assay used: EMIT | range 6 – 30m
| Analyzed: 115 after 6m | Other 3.4 | Methylpred.
| | Organ transplanted: Kidney (Renal) | Prednisone
| | Age: Mean 46 +/- 9y
| | Range 37–55y
| | % Male: 58.1
| | Weight: NR
Author: Braun | Aim: Assess the relationship between therapeutic drug monitoring and clinical course in kidney and liver recipients. | Population: patients receiving a tacrolimus based immunosuppressive regimen. | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: liver rejection
Year: 1998 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 30–40 mg/kg/day | Method of measurement: trough | dirrhea
Country: Germany | Study design: Prospective Cohort | Liver | Prospective dose adjustment planned: No | Frequency of MPA measure: Not reported | CMV infection
| Entered into study: 28 | Age: NR | Concomitant medications: Tacrolimus | Assay used: HPLC | G.I. symptoms
| Analyzed: 28 | % Male: NR | | MEIA II | Length of followup: median 280d
| | Weight: NR | | | range 19–585d
Author: Brunet | Aim: To determine whether MPA monitoring is advisable in liver transplant patients | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: diarrhea
Year: 2006 | Comparison of monitored patients with others: No | Organ transplanted: Liver | Dose: 1 g twice a day | Method of measurement: C_0_, C_max_, AUC_0–12_ | nausea
Country: Spain | Study design: Case series | Age: Range 29–66y | Prospective dose adjustment planned: Yes - based on clinical indicators | Frequency of MPA measure: day 6, 10, 16 month 3, 6 | Length of followup: 6m
| Entered into study: 15 | % Male: 60 | Concomitant medications: Tacrolimus | Assay used: HPLC
| Analyzed: day 6 n=13, | Weight: NR | Methylpred.
| day 10 n=13, | | Daclizumab
| day 16 n=14,
| month 3 n=10,
| month 6 n=13
Author: Brunet | Aim: Compare the MPA pharmacokinetic profile and its pharmacodynamic effect on petients recieving either standard (2 g) or low (1.5 g or 1 g) MMF doses, in order to evaluate the therapeutic efficiacy of such low doses in inhibiting IMPDH activity | Population: Stable renal tx recipients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: IMPDH
Year: 2000 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1 g, .075 g, and 0.5 g | Method of measurement: C_0_, C_max_, AUC_0–12_ | activity
Country: Spain | Study design: Case control | Age: Mean 42.5 +/- 13.6 y | Prospective dose adjustment planned: No | Frequency of MPA measure: NR | Length of followup: 38.5m
| Entered into study: 27 | Range 18–65y | Concomitant medications: Prednisone | Assay used: HPLC | (6–166m)
| Analyzed: 27 | % Male: NR | CsA
| | Weight: NR
Author: Brusa | Aim: Ascertain any correlation between MPA plasma concentrations in patients receiving an oral daily dose of the drug after an allograft renal transplantation, and a number of variables, such as time-course, drug dosage (fixed or per body weight), frequency | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: trough | Health outcome: serious side effects
Year: 2000 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 250 to 1000 mg/day BID | Method of measurement: trough | interstitial rejection
Country: Italy | Study design: Prospective Cohort | Age: Range: 18 patients 13–58y | Prospective dose adjustment planned: No | Frequency of MPA measure: once, immediately post tx OR in advanced therapy | Length of followup: >12m
| Entered into study: 23 | 5 patients 35–56y | Concomitant medications: Cyclosporine | Assay used: HPLC
| Analyzed: 23 | % Male: 83 | Corticosteroids
| | Weight: NR
Author: Bunchman | Aim: To evaluate the safety, tolerability and pharmacokinetics of MMF suspension in pediatric renal recipients | Population: 64 patients were from North America, 4 from Australia and 32 from Europe | Form given: Mycophenolate mofetil (MMF, CellCept) oral suspension | Form measured: MPA | Health outcome: acute rejection
Year: 2001 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m2 BID up to 1 g BID | MPAG | leucopenia
Country: USA | Study design: Prospective Cohort | Age: Inclusion requirement 3m – 18y | Prospective dose adjustment planned: Yes - based on clinical indicators 49% of patients experienced adverse events that resulted in MMF dose reduction or interuption | Method of measurement: AUC_(0–12h)_ | diarrhea
| Entered into study: 100 | % Male: 68 | Concomitant medications: Cyclosporine | Frequency of MPA measure: on day 7 and at 3, 9, 24 and 36 m | sepsis
| Analyzed: 72 | Weight: NR | Corticosteroids | Assay used: LC-MS liquid chromatography | abdominal pain
| | | | | fever
| | | | | Length of followup: 36m
Author: Cantin | Aim: To determine clinical relevance of MPA monitoring and examine its correlation with calcineurin antagonists and acute rejection | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: asymptomatic rejection
Year: 2002 | Comparison of monitored patients with others: No | Organ transplanted: Heart (Cardiac) | Dose: Tac group: 1810 mg/day +/- 817, CsA group: 2447 +/- 896 | MPAG | Length of followup: 1y
Country: USA | Study design: Case series | Age: Mean 54.4 +/- 14y | Prospective dose adjustment planned: No | Method of measurement: trough levels
| Entered into study: 26 | Range 22–72y | Concomitant medications: Cyclosporine | Frequency of MPA measure: NR
| Analyzed: 22 | % Male: 73 | Tacrolimus | Assay used: HPLC
| | Weight: NR | Corticosteroids
Author: Cattaneo | Aim: To optimize MMF dosing by monitoring MPA PK | Population: adult renal tx patients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: creatinine
Year: 2001 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 2 g/day | MPAG | anemia
Country: Italy | Study design: Case series | Age: Mean AUC >40 ug.ml h: 31.9 +/- 9.0y | Prospective dose adjustment planned: Yes - based on clinical indicators | Method of measurement: C_0_, AUC_0–12_ (as predicted by LSS AUC_0–2_) | Length of followup: 9m
| Entered into study: 46 | Mean AUC <40 ug.ml h: 39 +/- 12.4y | Concomitant medications: Cyclosporine | Frequency of MPA measure: NR
| Analyzed: 46 | Range 19–61y | Prednisone | Assay used: HPLC
| | % Male: 63 | CsA Neoral
| | Weight: Mean AUC >40 ug.ml h: 61.7 +/- 11.3kg,
| | Mean AUC <40 ug.ml h: 67 +/- 12.9kg
| | Range 44–97kg
Author: Deierhoi | Aim: Phase I trial: to study dose ranging and side effects Rescue trial: to study MMF as rescue therapy in acute rejection | Population: 55.9% black, 2% other, 43% white | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: diarrhea - phase 1 and rescue
Year: 1993 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: phase I: 1500 – 3000 mg/day rescue: 2000 mg/day and 3000–3500 mg/day if no response in first week to 2000 mg | Method of measurement: trough levels, peak concentration | nausea - phase 1 and rescue
Country: USA | Study design: Prospective Cohort | Age: Inclusion requirement phase I: older than 18, rescue: older than 16 | Prospective dose adjustment planned: Yes - based on clinical indicators side effects - phase I: diarrhea, rescue: diarrhea and nausea | Frequency of MPA measure: Day 1, 7, 14, 20 | elevated liver enzymes - phase 1
| Entered into study: Condition 1: | % Male: 54.8 | Concomitant medications: Cyclosporine phase I and rescue | Assay used: HPLC | Length of followup: phase I trial: mean 26m range 22 – 28m
| 21 phase I | Weight: NR | Methylpred. phase I | | rescue: mean 20m range 16 – 24m
| Condition 2: | | Prednisone rescue
| 100 quadruple therapy | | Corticosteroids phase I phase I and rescue: Minnesota antilymphocyte globulin(MALG)
| Condition 3: | | rescue: azathioprine
| 26 rescue therapy
| Condition 4:
| 39 steroid rescue
| Analyzed: Condition 1:
| 18 phase I
| Condition 2:
| NR quad therapy
| Condition 3:
| 25 rescue therapy
| Condition 4:
| NR steroid rescue
Author: DeNofrio | Aim: To determine the clinical significance of MPA concentrations following orthotopic heart transplantation (OHT) | Population: Tx patients with surveillance biopsy | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: rejection
Year: 2000 | Comparison of monitored patients with others: No | Organ transplanted: Heart (Cardiac) | Dose: 1g BID | fMPA | cardiac allograft
Country: USA | Study design: Case series | Age: Mean 53 +/- 10y | Prospective dose adjustment planned: No | Method of measurement: C_0_, C_max_, AUC_0–12_ (as predicted by LSS C_0_, C_20_, C_40_, C_75_, C_120_) | Length of followup: 310 ±278d
| Entered into study: 38 | % Male: 82 | Concomitant medications: Cyclosporine | Frequency of MPA measure: once on MMF
| Analyzed: 38 | Weight: NR | | Assay used: HPLC
Author: Dipchand | Aim: Review our experience with MMF dosing and the role of MPA levels for therapeutic drug monitoring in a population of pediatric heart transplant recipients | Population: Pediatric heart tx | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: rejection
Year: 2001 | Comparison of monitored patients with others: No | Organ transplanted: Heart (Cardiac) | Dose: various: 15–159 mg/kg | Method of measurement: Trough | Length of followup: 8w
Country: Canada | Study design: Retrospective Cohort | Age: Range 29d–23.5y | Prospective dose adjustment planned: required based on clinical indicators | Frequency of MPA measure: various: 1–7 levels
| Entered into study: 44 | Median 6.3y | Concomitant medications: Cyclosporine (A or neural) | Assay used: EMIT
| Analyzed: 44 | % Male: 61 | Tacrolimus
| | Weight: NR | Corticosteroids azathiaprine
| | | ATG
| | | OKT3
| | | ATS
Author: Filler | Aim: Replacing Aza with MMF in long term renal transplant recipients with evidence of CsA toxicity, thus allowing a safer reduction of CyA without an increased risk of rejection. | Population: Pediatric and adolescent renal tx recipients with chronic CyA toxicity | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: leucopenia
Year: 2000 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m2 BID | Method of measurement: C_0_ AUC_(0–12)_ | thrombocytopenia
Country: Germany | Study design: Case series | Age: Mean 17.2 y ± 4.3 SDy | Prospective dose adjustment planned: Yes - based on clinical indicators | Frequency of MPA measure: all = 21 days +/- 17; 1 to 4 profiles | diarrhea
| Entered into study: 18 | % Male: 50 | Concomitant medications: Cyclosporine | Assay used: HPLC | Length of followup: Mean 6.2 ± 2.7y
| Analyzed: 18 | Weight: NR | Steroids | EMIT | Range 2.3–11.8y
| | | Azathioprine(13 patients but weaned off in 2)
| | | ATG-induction (5 patients)
| | | Tacrolimus (1 patient due to resistance but weaned off soon after due to side effects)
Author: Filler | Aim: MMF with Tac for steroid-resistant vascular rejection in pediatric renal allografts | Population: Adolescent renal transplant recipients having an acute rejection episode. | Form given: Mycophenolate mofetil (MMF, CellCept) MMF | Form measured: MPA | Health outcome: renal graft losses
Year: 1998 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m2 BID reduced to 320 mg/m2/day over 7 wks | MPAG | severe diarrhea
Country: Germany | Study design: Case series | Age: Mean 15.8 +/- 1.6y | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels trough concentrations were used to adjust MMF doses | Method of measurement: C_0_ AUC_0–12_ | Length of followup: range 49–503d,
| Entered into study: 7 | Range 13 – 18y | Concomitant medications: Tacrolimus | Frequency of MPA measure: Repetetive blood sampling from before dose and then 9 more times after dosage in the next 12 hours. Drug monitoring was performed by the estimation of trough concentration and pharmacokinetic profile between days 10 and 18. | mean 282d
| Analyzed: 7 | % Male: 29% | Methylpred. | Assay used: HPLC
| | Weight: Not reported
Author: Flechner | Aim: To determine efficacy & side effects of low dose (1 g) MMF in a CNI drug avoidance regimen including sirolimus/steroids | Population: White 79%, Black 18%, Others 3% | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: Acute rejections
Year: 2005 | Comparison of monitored patients with others: Yes versus clinically driven dose changes | Organ transplanted: Kidney (Renal) | Dose: 1g BID (n=160) and 500 mg BID (n=100) | Method of measurement: Co level | CMV infections
Country: USA | Study design: Prospective Cohort | Age: Mean 48.5 | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels | Frequency of MPA measure: At 2wks, 1m, 3m and 6m | Polyoma (BK) viral infections
| Entered into study: Condition 1 160 | % Male: 66.5 | Concomitant medications: Methylpred. | Assay used: HPLC | GI complaints Nausea/vomitting/dyspepsia, abdomenal pains, and diarrhea.
| Condition 2 100 | Weight: NR | Basiliximab | | Length of followup: 6m
| Analyzed: Condition 1 160 | | Sirolimus
| Condition 2 100 | | Diltiazem
| | | Thymoglobulin
Author: Gajarski | Aim: To determine correlation between MMF dose and MPA level and impact on rejection among young cardiac receipients | Population: 16 children, 10 adults | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: biopsy grades
Year: 2004 | Comparison of monitored patients with others: No | Organ transplanted: Heart (Cardiac) | Dose: average 1206.8 +/- 301.9 mg/m2 and 37.9 +/- 12.5 mg/kg | MPAG | Length of followup: NA
Country: USA | Study design: Case series | Age: Mean 15.4 +/- 9.5y | Prospective dose adjustment planned: No | Method of measurement: C_0_
| Entered into study: 26 | Range 1 m–33y | Concomitant medications: Cyclosporine | Frequency of MPA measure: NR
| Analyzed: 26 | % Male: NR | Tacrolimus | Assay used: HPLC
| | Weight: NR
Author: Gonzales-Roncero | Aim: To determine the effects of renal insufficiency on PK of MMF | Population: Cadaveric donor renal tx patients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: renal insufficiency
Year: 2005 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: group I: 185 +/- 0.2 g/day | MPAG | Length of followup: >1y
Country: USA | Study design: Prospective Cohort | Age: NR | group II: 1.7 +/- 0.5 g/day | free MPA
| Entered into study: Condition 1 10 | % Male: NR | Prospective dose adjustment planned: No | Method of measurement: AUC_(0–12h)_
| Condition 2 10 control | Weight: NR | Concomitant medications: Cyclosporine | Frequency of MPA measure: 0, 20, 40, 75 minutes 1, 2, 3, 4, 6, 8, 10, 12 hours after MMF dose
| Analyzed: Condition 1 10 | | | Assay used: HPLC/UV
| Condition 2 10 control
Author: Grasser | Aim: Present a nonblinded, nonrandomized long-term followup study to evaluate MPA trough level measurement for the quidance of MMF rejection prophylaxis after Liver TX. | Population: adult liver tx recipients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: SGOT
Year: 2001 | Comparison of monitored patients with others: No | Organ transplanted: Liver | Dose: NR: Target concentration = 1ug/mL | Method of measurement: trough | SGPT
Country: Austria | Study design: Case series | Age: Mean 56y | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels | Frequency of MPA measure: daily for 2 weeks, then every other week | Bilirubin
| Entered into study: 11 | Range 27–70y | Concomitant medications: Methylpred. | Assay used: EMIT | Leucopenia
| Analyzed: 10 | % Male: 73 | Orednisone | | Length of followup: 6m
| | Weight: NR | horse ATG
| | | Apredisolone
Author: Hale | Aim: Confirm the observed pharmacokinetic-pharmacodynamic relationship by studying the relationship between MPA PF and the likelihood of rejection | Population: Recipients of 1st or 2nd kidney; 140 of 150 were caucasian | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: Acute rejection
Year: 1998 | Comparison of monitored patients with others: Three target MPA AUC values compared | Organ transplanted: Kidney (Renal) | Dose: L: 0.45 g BID then adj I: 0.95 g BID then adj H: 1.7 g BID then adj | Method of measurement: C_0_ C_max_ AUC_0–12_ | adverse events (vomit, abdominal pain, diarrhea, leukopenia, pneumonia)
Country: Netherlands, Belgium | Study design: RCT | Age: Inclusion requirement | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels | Frequency of MPA measure: day 3,7,11,21,28 week 8,12,16,20 | Length of followup: 6m
| Entered into study: Condition 1 L: 51 | > 18y | Concomitant medications: Cyclosporine | Assay used: HPLC
| Condition 2 I: 47 | Range | Corticosteroids
| Condition 3 H: 52 | L: 47.8 +/- 11.5; | Prednisone
| Analyzed: Condition 1 L: 29 | I: 46.9 +/- 13.8;
| Condition 2 I: 28 | H: 50.6 +/- 10.5
| Condition 3 H: 20 | % Male: L: 58.8;
| | I: 63.8;
| | H: 59.6
| | Weight: L: 69.8 +/- 12.5
| | I: 65.9 +/- 13/1
| | H: 67.4 +/- 11.3
Author: Hazzan | Aim: To compare incidence of acute rejection after withdrawal from CsA or MMF | Population: BMI CsA group 23.3 +/- 3.9, MMF group 24.0 +/- 11.2 | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2005 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: CsA group MMF dose = 1.93 +/- 0.2 then withdrawn to 0, MMF group MMF dose = 1.99 +/- 0.1 | Method of measurement: AUC_(0–12)_ C_0_ | Length of followup: 1y
Country: France | Study design: RCT | Age: Mean CsA group 42.5 +/- 12.1 | Prospective dose adjustment planned: No | Frequency of MPA measure: Once at 3 m
| Entered into study: CsA group: 54 | MMF group 45.1 +/- 11.2 | Concomitant medications: Cyclosporine | Assay used: Enzyme
| MMF group: 54 | % Male: 63 | Prednisone
| Analyzed: CsA group: 54 | Weight: NR
| MMF group: 54
Author: Heller | Aim: Study the relation of plasma concentrations of AcMPAG and MPAG with the incidence of diarrhea | Population: | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA, MPAG, AcMPAG | Health outcome: Diarrhea
Year: 2007 | Comparison of monitored patients with others: No | Organ transplanted: Kidney | Dose: Fixed Dose group: 1 g BID, Controlled Concentration group: target concentration of 30–60 mg*h/L | Method of measurement: Abbreviated AUC (0, 30m, 2h) | Length of followup: 12m
Country: Germany | Study design: Prospective Cohort | Age: 53.4y | Prospective dose adjustment planned: Yes, based on MPA (or metabolite) blood levels | Frequency of MPA measure: Day 3, 10, week 4, months 3, 6 and 12
| Entered into study: 290 | % Male: 62 | Concomitant medications: Cyclosporine | Assay used: HPLC initially then later, LC-MS
| Analyzed: 290 | Weight: NR | Tacrolimus
Author: Hesse | Aim: To evaluate the need for routine monitoring of MPA trough plasma levels to prevent acute rejection in heart transplant recipients | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection biopsy score
Year: 2001 | Comparison of monitored patients with others: No | Organ transplanted: Heart (Cardiac) | Dose: 1500 mg BID + dose reductions on clinical symptoms | Method of measurement: C_0_ | Length of followup: Mean 10.1m
Country: Netherlands | Study design: Case series | Age: NR | Prospective dose adjustment planned: Yes - based on clinical indicators | Frequency of MPA measure: at biopsy
| Entered into study: 20 | % Male: NR | Concomitant medications: Tacrolimus | Assay used: EMIT
| Analyzed: 20 | Weight: NR | Prednisone
| | | CsA
Author: Hubner | Aim: To determine the relationship between MMF side effects and MPA trough levels in renal transplant patients | Population: adult renal tx recipient | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2000 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1.0 g twice a day | Method of measurement: Predose concentration | leucocyte count
Country: Germany | Study design: Case series | Age: Mean 45y | Prospective dose adjustment planned: Yes - based on clinical indicators adverse events | Frequency of MPA measure: 3–4 times a wk for the first month, once a wk during the second month and once a month thereafter | other adverse reactions (cytomegalovirus infection, pneumonia, urinary tract infection, herpes zoster, infected hematoma, pancreatitis, leucopenia)
| Entered into study: 30 | % Male: 66.7 | Concomitant medications: Cyclosporine | Assay used: EMIT | Length of followup: NR
| Analyzed: 30 | Weight: Mean for entire population mean body weight 73 kg | Methylpred.
Author: Johnson | Aim: To determine whether MPA kinetics vary after renal trasplantation and to examine the potenial role of enterohepatic recirculation. | Population: consecutive kidney transplant recipients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: creatinine
Year: 1999 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | MPAG | albumin
Country: Australia | Study design: Case series | Age: Mean 41.7 +/- 5.0y | Prospective dose adjustment planned: No | Method of measurement: AUC_(0–12H)_ | Length of followup: 28d
| Entered into study: 10 | % Male: 60 | Concomitant medications: Cyclosporine | tmax
| Analyzed: 10 | Weight: NR | Methylpred. | array of limited sampling
| | | ranitidine | Frequency of MPA measure: day 2, 5, 28
| | | sulfamethoxazole/trimethoprim | Assay used: HPLC
| | | iron supplements
| | | amphotericin lozenges
| | | diltiazem
| | | calcitrol
Author: Johnson | Aim: The purpose of this study was to determine the effect of renal function on the elimination and disposition of MPA and its MPAG after oral administration of the pro-drug MMF,and to examine hemodialysis removal of MPA and its MPAG. | Population: Patients with varing degree of renal function | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA, MPAG | Health outcome: elimination and disposition of MPA and its MPAG, Hemodialysis removal of MPA and its MPAG
Year: 1998 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1 g | Method of measurement: Maximum concentration, Full AUC_(0–24h)_ and AUC_(0–96h)_ | Length of followup: 96h
Country: USA | Study design: Case control | Age: 44.5 +/- 15.9, 41.7+/- 10.3, 43.8 +/- 10.8, 45.3 +/- 15.0, 45.3 +/- 8.5 respectively in Groups 1–5 | Prospective dose adjustment planned: No | Assay used: HPLC
| Entered into study: 31 | % Male: 74 | Concomitant medications: None | Frequency of MPA measure: 24 h and 96 h after administration
| Analyzed: 31 | 83.3, 66.6, 100, 57.1,66.6 respectively in Groups 1–5
| | Weight: 80.2 +/- 10.3, 74.9 +/- 15.6, 103.7 +/- 31.2, 81.8 +/- 19.0, and 72.7 +/- 12.1 respectively in groups 1–5
Author: Kaplan | Aim: To examine the protein binding and free concentrations of MPA in 23 adult renal transplant patients, 8 of whom had chronic renal insufficiency | Population: 23 Renal transplant recipients; 8 with chronic renal insufficiency | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: adverse events
Year: 1999 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1.75 +/- 0.3 g/day | MPAG | leucopenia
Country: USA | Study design: Case series | Age: Range 46.7 +/- 9.2 y for chronic renal subjects | Prospective dose adjustment planned: No | fMPA | abdominal pain
| Entered into study: 23 | 43.3 +/- 8.6 For renal patients without chronic insufficiency | Concomitant medications: NR | Method of measurement: abbreviated AUC_0–12_ (based on LSS of C_0_, C_20_, C_40_, C_75_, C_120_) | Length of followup: >2w
| Analyzed: 23 | % Male: 37.5 | | Frequency of MPA measure: once (>2wk)
| | Weight: NR | | Assay used: HPLC
Author: Kiberd | Aim: To examine whether early exposure to MPA predicts later outcomes | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2004 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 2 g/day fixed | Method of measurement: C_0_ C_2_ AUC_0–12_ (as predicted by LSS of C_0_, C_1_, C_2_, C_4_) | toxicity
Country: Canada | Study design: Case series | Age: Mean 48 +/- 13y | Prospective dose adjustment planned: Yes - based on clinical indicators | Frequency of MPA measure: day 3, 5, 7 and up to 3m | Length of followup: 3m
| Entered into study: 94 | % Male: 70 | Concomitant medications: Prednisone | Assay used: HPLC
| Analyzed: day 3: 94, | Weight: NR | Neoral
| day 5: 86,
| day 7: 58
Author: Kreis | Aim: Evaluate the clinical activity and safety of sirolimus in association with MMF and steriods compared with CsA-MMF steroid therapy in human renal transplantation | Population: First renal tx recipients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: trough VS rejection
Year: 2000 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1g BID | Method of measurement: trough | Length of followup: 6m
Country: 14 European centres | Study design: RCT | Age: Range for entire population SIR: 43.5 +/- 10.9 (22–62); CsA: 42.9 +/- 11.4 (18–60) | Prospective dose adjustment planned: No | Frequency of MPA measure: weekly
| Entered into study: Condition 1 SIR: 40 | % Male: Entire population SIR: 70; CsA: 71 | Concomitant medications: Cyclosporine | Assay used: EMIT
| Condition 2 CsA: 38 | Weight: NR | Corticosteroids
| Analyzed: Condition 1 SIR: 40 | | Sirolimus
| Condition 2 CsA: 38
Author: Krumme | Aim: Whether blood levels of MPA have an impact on the outcome after renal transplantation, such as on the incidence of acute rejection as well as on the incidence of infection | Population: Consecutive renal tx recipients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: rejection
Year: 1998 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1g BID | Method of measurement: trough levels | infection
Country: Germany | Study design: Case series | Age: Range 46 +/-11y | Prospective dose adjustment planned: Yes based on MPA plasma levels and clinical indicators | Frequency of MPA measure: 6 to 24 samples/patient | urinary infection
| Entered into study: 48 | % Male: 71 | Concomitant medications: Cyclosporine | Assay used: EMIT | Length of followup: 2m
| Analyzed: 48 | Weight: NR | Methylpred.
Author: Kuriata - Kordek | Aim: To investigate the realtionship between PK of MPA and risk of developing adverse events or acute rejection | Population: all adult kidney tx recipients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2002 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 2.0 g/day | Method of measurement: C_0_, C_40_, C_60_, C_120_, C_max_ | side effects
Country: Poland | Study design: Case control | Age: Inclusion requirement group I: 38.12 +/- 9.5 y, group II: 38.52 +/- 9.21y | Prospective dose adjustment planned: No | Frequency of MPA measure: 14 days – 12 months | leucopenia
| Entered into study: Condition I: 12 patients with acute rejection | % Male: 38.5 | Concomitant medications: Cyclosporine | Assay used: HPLC | anemia
| Condition II: 27 patients without acute rejection | Weight: Group I: 68.46 +/- 11.23, | Prednisone | | GI symptoms
| Analyzed: NR | Group II: 62.89 +/- 12.41 | | | Length of followup: 12m
Author: Kuypers | Aim: To examine whether the PK parameter of tac and MPA reflect their clinical efficacy | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2004 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 0.5 g BID or 1 g BID | Method of measurement: C_0_ C_max_ AUC_0–12_ | infection
Country: Belgium | Study design: Case series | Age: Mean for entire population median 51.5y | Prospective dose adjustment planned: Yes based on clinical indicators | Frequency of MPA measure: day 7, 42, 90, 180, 360 and month 3, 6, 12 | leucopenia
| Entered into study: 100 | % Male: 59 | Concomitant medications: Tacrolimus | Assay used: EMIT | anemia
| Analyzed: NR | Weight: Mean 69.2 +/- 13.1 kg at baseline | Methylpred. | | Length of followup: 12m
| | | Daclizumab
Author: Kuypers | Aim: To identify a possible relation between PK of MPA adn clinical outcomes | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: rejection
Year: 2003b | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | MPAG | diarrhea
Country: Belgium | Study design: Non-randomized controlled trial | Age: Mean 49.4 +/- 13.1y | Prospective dose adjustment planned: No | AcMPAG | leucopenia
| Entered into study: 33 | % Male: 57.6 | Concomitant medications: Tacrolimus | fMPA | anemia
| Analyzed: 33 | Weight: NR | Daclizumab | Method of measurement: C_0_, C_max_, AUC_0–12_ (as predicted by LSS of C_0_, C_40m_, C_2h_) | Length of followup: 12m
| | | Methylpredisolone | Frequency of MPA measure: day 3, 7, 10, 14, 28, week 6, 8, 10, 12, 14, month 4,6, 9, 12
| | | | Assay used: HPLC
Author: Kuypers | Aim: To assess whether long term changes in MPA exposure and Tac and corticosteroids are dose dependent and not reflected through plasma concentration | Population: >17 and received a primary or secondary cadaberic donor kidney | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: biopsy proven rejection
Year: 2003a | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1 g/day or 2 g/day | Method of measurement: C_0_, C_max_, AUC_0–12_ | survival
Country: Belgium | Study design: Non-randomized controlled trial | Age: Mean for entire population meidan 51.5y | Prospective dose adjustment planned: No | Frequency of MPA measure: day 7, week 6, month 3 and 12 | diarrhea
| Entered into study: 100 | % Male: 59 | Concomitant medications: Methylpredisolone | Assay used: EMIT | Length of followup: 12m
| Analyzed: NR | Weight: Mean 69.2 +/- 13 | Tacrolimus
| | | Daclizumab (31 patients)
Author: Le Meur | Aim: Trial of recipients randomized to receive either FD MMF or a CC regimen in which MMF dose adjustments were calculated to reach predefined MPA target levels | Population: Consecutive recipients of a first or second allograft | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: Treatment failure (composite of death, graft loss, acute refection and MMF discontinuation)
Year: 2007 | Comparison of monitored patients with others: Yes, versus predetermined dosage schedule | Organ transplanted: Kidney | Dose: FD: 1 g BID | Method of measurement: Abbreviated AUC: 20m, 1h, 3h | Acute rejection
Country: France | Study design: RCT | Age: CC group: 50 +/- 14 | CC: Days 1–7, 1 g BID, then target dose = 40 mg*h/L | Frequency of MPA measure: Days 7, 14, months 1, 3, 6, 12 | Adverse events
| Entered into study: CC: 70 | FD group 49 +/- 13 | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels | Assay used: HPLC | Length of followup: 12m
| FD: 67 | % Male: CC group: 71 | Concomitant medications: Cyclosporine
| Analyzed: CC: 65 | FD group 58 | Methylpred.
| FD: 65 | Weight: NR | Basiliximab
| | | Trimethoprim-sulfamethoxazole
Author: Lu | Aim: To assess influence of CsA and Tac on MPA and correlate PK parameters, patient characteristics and clinical outcomes | Population: Chinese recipients of a 1^st^ kidney | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2005 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1000 mg BID | Method of measurement: AUC_(0–12h)_ | Length of followup: 1m
Country: China | Study design: Non-randomized clinical trial | Age: Mean 40.0 +/- 12.0y | Prospective dose adjustment planned: No | Frequency of MPA measure: NR
| Entered into study: 29 | % Male: 58.6 | Concomitant medications: Cyclosporine | Assay used: HPLC
| Analyzed: 29 | Weight: Mean 58.0 +/- 10.0 kg | Prednisone
| | | Tacrolimus
Author: Lu | Aim: To investigate the relationship between clinical events and the PK of MPA in adult renal transplant patients. | Population: first cadaveric renal transplantation | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection (biopsy proven)
Year: 2006 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: weight directed dosage (50 kg: 2.0 g/day) starting 2 days before transplantation | Method of measurement: C_0_ C_max_ C_60_ AUC_0–12_ | infection in different organs with various pathogens,
Country: China | Study design: Case series | Age: Mean 34.1 + - 7.1y | Prospective dose adjustment planned: Yes - based on clinical indicators dose adjusted according to drug tolerance and related side effects | Frequency of MPA measure: MMF PK profiles from 0 (predose or Cmin), 0.4 (C 30), 1 (C60). 1.5, 2, 2.5, 4, 6, 8, 10, 12 hour samples. MMF trough concentrations measured before MMF dosage on day 4, 7, 21, & 28 as well as 1.5, 2, 3, and 6 months. | hematologic events, mainly leukopoenia and thrombocytopenia, GI symptoms, none of which were severe diarrhea
| Entered into study: 37 | Range 18 to 64y | Concomitant medications: Cyclosporine CsA, Neoral steroids | Assay used: HPLC | Length of followup: 6m
| Analyzed: 37 | % Male: 65% | | ROC curve analysis
| | Weight: Inclusion requirement
Author: Lu | Aim: To investigate relation between clinical events and PK of MPA in Chinese kidney transplant recipients | Population: Adults of first cadaver kidney tx | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: toxicity
Year: 2004 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: weight directed 50 kg | Method of measurement: Predose concentration AUC_(0–12h_) | acute rejection
Country: China | Study design: Case series | Age: Mean 36 +/- 7.1y | 2 g/day | Frequency of MPA measure: 2 days before transplant, 14 days after transplant | Length of followup: 6m
| Entered into study: 22 | Range 18–57y | Prospective dose adjustment planned: Yes - based on clinical indicators | Assay used: HPLC
| Analyzed: 22 | % Male: 54.5 | Concomitant medications: Cyclosporine | RP-HPLC
| | Weight: Not reported
Author: Maes | Aim: To explore GI tract in MMF treated patients with diarrhea | Population: Transplant recipients with persistent afebrile diarrhea | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: bile acid malabsorption
Year: 2003 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1.6 +/- 0.5 g/day, range 1 – 3 g/day | MPAG | colonic transit time
Country: Belgium | Study design: Case series | Age: Mean 46 +/- 15y | Prospective dose adjustment planned: No | AcMPAG | infection
| Entered into study: 26 | Range 18 – 70y | Concomitant medications: Cyclosporine | free MPA | Length of followup: 2y
| Analyzed: 26 | % Male: 46.2 | Tacrolimus | Method of measurement: C_0_
| | Weight: Mean 66.8 +/- 13.8 | Methylpred. | Frequency of MPA measure: NR
| | | | Assay used: NR
Author: Mandla | Aim: TDM of MPA with CsA ar Tac was investigated in renal tx patients | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2006 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1g 2 times day in combined kidney plus pancreas transplant patients 1 g 3 times a day | MPAG | Length of followup: 3m
Country: Norway | Study design: Non-randomized Controlled Trial | Age: Mean 54y | Prospective dose adjustment planned: Yes - based on clinical indicators | Method of measurement: Predose concentration
| Entered into study: Condition 1 68 CsA | Range 19 –77y | Concomitant medications: Cyclosporine | Frequency of MPA measure: 2–3/wk for first 4 wks, then 1–2/wk up to 3 months
| Condition 2 10 Tac | % Male: 73.1 | Tacrolimus | Assay used: HPLC
| Analyzed: 78 | Weight: Mean 74 kg | Methylpred. | Automated sequential trace enrichment of dialysis
| | Range 49–139 | Prednisone
Author: Meiser | Aim: To investigate the efficacy of Tac and MMF combination therapy as primary immunosupression. | Population: Consecutive patients undergoing primary orthotopic cardiac transplantation | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: rejection survival
Year: 1999a | Comparison of monitored patients with others: Phase I, fixed dose patients compared to phase II, patients with dose adjusted for MPA level | Organ transplanted: Heart (Cardiac) | Dose: Phase I 1 g BID, Phase II target level 2.5 to 4.5 ug/mL | Method of measurement: C_0_ | Length of followup: Phase I: 522 (432–616)d, Phase II: 273 (133–388)d
Country: Germany | Study design: Non-randomized Controlled Trial | Age: Inclusion requirement >18y | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels Phase II | Frequency of MPA measure: Daily X 3 weeks, then biweekly
| Entered into study: Condition 1 Phase I 15 | Mean Phase I 50.6 +/- 11.4, Phase II 54.01 +/- 8.9 | Concomitant medications: Tacrolimus | Assay used: EMIT
| Condition 2 Phase II 30 | Range Phase I 18–64, Phase II 21–66 | Methylpred.
| Analyzed: Condition 1 Phase 1 15 | % Male: Phase I 87%, Phase II 77% | Prednisone
| Condition 2 Phase II 30 | Weight: NR
Author: Meiser | Aim: Assess the efficacy of Tac and mycophenolate as primary therapy following cardiac transplantation | Population: consecutive patients undergoing orthotopic cardiac transplantations | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: rejection toxicity
Year: 1999b | Comparison of monitored patients with others: Phase I, fixed dose patients compared to phase II, patients with dose adjusted for MPA level | Organ transplanted: Heart (Cardiac) | Dose: Phase I: 1 g/day BID | Method of measurement: C_0_ | Length of followup: Phase I: 696 ± 62d (606–790)
Country: Germany | Study design: Non-randomized Controlled Trial | Age: Inclusion requirement Phase I & II: >18y | Phase II: 2.5 to 4.5 ug/ml | Frequency of MPA measure: Phase I: NR | Phase II: 436 ± 88d (175–562)
| Entered into study: Condition 1 Phase I: 15 | Range Phase I: 50.6 +/- 11.4 (18–64); Phase II: 54.1 +/- 8.9 (21–66) | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels Phase II | Phase II: Monthly
| Condition 2 Phase II: 30 | % Male: Phase I: 87; phase II: 77 | Concomitant medications: Tacrolimus | Assay used: EMIT
| Analyzed: Condition 1 Phase I: 15 | Weight: NR | Prednisone
| Condition 2 Phase II: 30 | | Methylpred.
Author: Merkel | Aim: To use MMF to prevent rejection in renal transplant patients | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection drug reactions (diarrhea)
Year: 2005 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 0.5–1.0 g BID | MPAG | Length of followup: 16m, mean 5.7m
Country: Germany | Study design: Retrospective Cohort | Age: Mean 44 +/- 13.6y | Prospective dose adjustment planned: No | Method of measurement: trough levels
| Entered into study: 35 | Range 13– 63y | Concomitant medications: Cyclosporine | Frequency of MPA measure: NR
| Analyzed: 35 | % Male: 68.6 | Prednisone | Assay used: HPLC
| | Weight: Mean 72.9 +/- 14.3 | Corticosteroids
| | Range 47–104
Author: Morgera | Aim: MMF PK in renal transplant recipients on peritoneal dialysis. | Population: Early post transplant patients on dialysis | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: GFR
Year: 1998b | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1 g BID; Two 12 hour periods, once before and once after peritoneal dialysis. | MPAG | Length of followup: 2d
Country: Germany | Study design: Prospective Cohort | Age: Range 25 – 60y | Prospective dose adjustment planned: No | Method of measurement: NR
| Entered into study: Condition 1 delayed graft function n=3 | % Male: 20% | Concomitant medications: Cyclosporine | Frequency of MPA measure: Before and 8 times after dosage in 12 hour period
| Condition 2 recovering renal function n=2 | Weight: NR | Methylpred. | Assay used: HPLC semi-automatic
| Analyzed: Condition 1 delayed graft function n=3 | | Oxacillin
| Condition 2 recovering renal function n=2
Author: Morgera | Aim: PK of MMF in renal transplant patients on dialysis | Population: Early post transplant patients on dialysis | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: GFR
Year: 1998a | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1 g BID; Two 12 hour periods, once before and once after peritoneal dialysis. | MPAG | Length of followup: 2d
Country: Germany | Study design: Case series | Age: Range 25 to 60y | Prospective dose adjustment planned: No | Method of measurement: NR
| Entered into study: Condition 1 delayed graft function n=3 | % Male: 20% | Concomitant medications: Cyclosporine | Frequency of MPA measure: before and 8 times after dosage in 12 hour period
| Condition 2 recovering graft function n=2 | Weight: NR | Methylpred. | Assay used: HPLC
| Analyzed: Condition 1 delayed graft function n=3 | | Oxacillan
| Condition 2 recovering graft function n=2
Author: Mourad | Aim: Assess the pharmacokinetic/pharmacodynamic (PK/PD) relationship for MPA in kidney transplant patients recieving low-dose MMF (500 mg twice a day) in combination with Tac. | Population: Adult, kid tx on low dose MPA | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: rejection side effects thrombo-cytopenia esophagitis lecopenia anemia
Year: 2001b | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 500 mg BID + adjustment for side effects | Method of measurement: | GI symptoms
Country: Belgium | Study design: Case series | Age: Range 32–68y | Prospective dose adjustment planned: Yes - based on clinical indicators | Frequency of MPA measure: Immediate stabilized if side effect or rejected + 3m | Diarrhea
| Entered into study: 51 | Median 49y | Concomitant medications: Tacrolimus | Assay used: EMIT | Length of followup: 3m
| Analyzed: 51 | % Male: 57 | Corticosteroids
| | Weight: NR
Author: Mourad | Aim: Investigate the relationship between the clinical events and the PK of MPA in adult renal transplantation | Population: Adult kidney tx | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: side effects rejection esophagitis leucopenia diarrhea anemia thrombo-cytopenia
Year: 2001a | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Method of measurement: C_0_, C_30m_, AU_C0–12_ | Length of followup: 3m
Country: Belgium | Study design: Case series | Age: Mean 43y | Prospective dose adjustment planned: Yes - based on clinical indicators | Frequency of MPA measure: early after tx, 3 months and at every clinical event
| Entered into study: 31 | Range 16–67y | Concomitant medications: Cyclosporine anti-thymocyte globulin steroids | Assay used: EMIT
| Analyzed: 31 | % Male: 55 (17/31) | | HPLC
| | Weight: NR
Author: Mourad | Aim: Evaluate the analytical performances of this new EMIT assay, to determine the main PK parameters of MPA in renal transplantation, and finally, to evaluated a possible relationship between pharmacodynamics and pharmacokinetics of MPA (correlation) | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection side effects
Year: 2000 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1g BID | Method of measurement: C_0-_ AUC_0–12_, | Length of followup: 12w
Country: Belgium | Study design: Case series | Age: Mean 46y | Prospective dose adjustment planned: No | Frequency of MPA measure: week 1, 4, 12
| Entered into study: 7 | Range 33–57y | Concomitant medications: Cyclosporine prednisolone | Assay used: EMIT
| Analyzed: 7 | % Male: 29
| | Weight: NR
Author: Mudge | Aim: To study the effect of iron on MMF absorption in renal transplant patients | Population: white 98%, BMI 25.1 +/- 3.7 kg/m2; only adults | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection toxicity
Year: 2004 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Method of measurement: AUC_0–12_(as predicted by LSS of C_0_, C_1_, C_3_, C_6_) | GI symptoms
Country: Australia | Study design: RCT | Age: Mean 45.2 +/- 13.2y | Prospective dose adjustment planned: No | Frequency of MPA measure: day 5 | Length of followup: 7m
| Entered into study: 45 | % Male: 55 | Concomitant medications: Cyclosporine | Assay used: HPLC
| Analyzed: 40 | Weight: NR | Tacrolimus
| | | Prednisone
Author: Naesens | Aim: To determine the relationship between single nucleotide polymorphisms in the MRP2 genes and MPA PK | Population: caucasian de novo renal allograft recipients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: liver dysfunction
Year: 2006 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 0.5 or 1 g BID | Method of measurement: CL/F apparent steady-state total body clearance | Length of followup: 360d
Country: Belgium | Study design: Prospective Cohort | Age: Inclusion requirement >17 | Prospective dose adjustment planned: Yes - based on clinical indicators | Frequency of MPA measure: day 7(12 hour AUC), day 42(2 hour AUC), day 90(4 hour AUC), day 360(4 hour AUC)
| Entered into study: Condition 1 MRP2 carriers 41 | Mean 51.3 +/- 14.1y | Concomitant medications: Tacrolimus | Assay used: EMIT
| Condition 2 MRP2 non carriers 54 | % Male: 60 | Corticosteroids
| Analyzed: Condition 1 MRP2 carriers 41 | Weight: Mean 68.7 +/- 13.4 kg | Daclizumab for 29 subjects
| Condition 2 MRP2 non carriers 54 | | Oral Methylpred.
Author: Naito | Aim: To obtain information on PK of MPA/MPAG and their interactions with CNIs | Population: Japanese renal tx recipients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: serum creatinine
Year: 2006 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 250–1750 mg/day | MPAG | Length of followup: >6m
Country: Japan | Study design: Non-randomized Controlled Trial | Age: Range 14 – 60y | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels | Method of measurement: correlation between MMF dose
| Entered into study: 9 in Tac group, | % Male: 64 | Concomitant medications: Cyclosporine | Blood Co Regression analysis
| 3 in CNI group, | Weight: Mean 59.2 kg | Tacrolimus | Frequency of MPA measure: NR
| 13 in CsA group | | | Assay used: HPLC
| Analyzed: NR
Author: Okamoto | Aim: To analyze usefulness of monitoring MPA to optimize therapy | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection infection
Year: 2005 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 25 mg/kg initially, then adjusted afterwards | Method of measurement: C_o_, AUC_0–9_ | GI
Country: Japan | Study design: Non-randomized Controlled Trial | Age: Mean 38 +/- 14y | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels and on adverse events and TDM | Frequency of MPA measure: 2 weeks and 4 weeks after transplant | Length of followup: NR
| Entered into study: 67 | % Male: NR | Concomitant medications: Cyclosporine n=35 | Assay used: EMIT 2000
| Analyzed: Entire population 67 (PK studies of MPA performed in 46 patients) | Weight: NR | Tacrolimusn=32
Author: Orlando | Aim: Increase 1.5 g/day MMF to 2 g/day in patients with CNI chronic toxicity. | Population: Adult liver transplanted patients with CNI related adverse effects. | Form given: Mycophenolate mofetil (MMF, CellCept) MMF | Form measured: MPA | Health outcome: renal function
Year: 2006 | Comparison of monitored patients with others: No | Organ transplanted: Liver | Dose: 250 mg per os BID increased weekly by 500 mg to dose of 1500 mg/day | Method of measurement: C_0_ | creatinine levels trigycerides
Country: Italy | Study design: Case series | Age: Mean 60.1y | Prospective dose adjustment planned: Yes - based on clinical indicators With a diagnosis of AR then MMF dose was adapted | Frequency of MPA measure: monthly | cholesterol
| Entered into study: 42 | Range 35 – 67y | Concomitant medications: Cyclosporine | Assay used: EMIT 2000 | diastolic
| Analyzed: 41 | % Male: 81% | Tacrolimus | | blood pressure
| | Weight: NR | | | acute rejection
| | | | | Length of followup: mean 61.5 ± 6.1m
Author: Pape | Aim: To determine whether long term monitoring in pediatric renal graft recipients improves quality of immunosuppression | Population: Children and adults - min 1y after renal tx | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: NR
Year: 2004 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m2 BID | Method of measurement: Predose concentration | Length of followup: 2y
Country: Germany | Study design: Case series | Age: Mean for entire population median 9.4y | Prospective dose adjustment planned: No | Frequency of MPA measure: every 3 months
| Entered into study: 42 | Range 1.4 – 15.1y | Concomitant medications: Cyclosporine | Assay used: LC-MS
| Analyzed: NR | % Male: 64.3 | Prednisone
| | Weight: NR
Author: Pawinski | Aim: To examine the ability of PK to discriminate between patients with and without acute rejection | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2006a | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | MPAG | Length of followup: 3m
Country: Poland | Study design: Case series | Age: Mean 48y | Prospective dose adjustment planned: No | Method of measurement: C_0_, C_max_, AUC_0–12_
| Entered into study: 51 | Range 17–62y | Concomitant medications: Cyclosporine | Frequency of MPA measure: at day 7, 6 – 8 weeks and 3 m
| Analyzed: 51 | % Male: 52.9 | Tacrolimus | Assay used: HPLC
| | Weight: NR | Prednisone
Author: Pawinski | Aim: To investigate the effect of time on PK of MPA in early post transplant period | Population: Adult renal tx recipients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2006b | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 0.5 – 2 g/day | MPAG | leucocyte cell count
Country: Poland | Study design: Case series | Age: Range 17–62y | Prospective dose adjustment planned: Yes - based on clinical indicators toxicity | Method of measurement: C_0_, AUC_0–2_, AUC_0–12_ concentration | hemotocrit
| Entered into study: 33 | % Male: 45.5 | Concomitant medications: Cyclosporine | Frequency of MPA measure: 1wk, 2m, 3m | Length of followup: 3m
| CsA: 23 patients | Weight: Range 40–86 kg | Tacrolimus | Assay used: HPLC
| Tac: 10 patients | | Prednisone
| Analyzed: 33
Author: Pillans | Aim: Assess the relationship between a single four-point MPA AUC measurement performed in the first week after transplant, as well as median trough cyclosporin concentration before rejection or during the first month and clinical outcomes in the first month. | Population: Caucasian from single center | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: Biopsy-proven acute rejection
Year: 2001 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 2 g/day | Method of measurement: C_0_ AUC_0–12_(as predicted by LSS C_0_, C_1_, C_3_, C_6_) | Gastrointestinal adverse events
Country: Australia | Study design: Case series | Age: Range 21–65 y | Prospective dose adjustment planned: No | Frequency of MPA measure: once (day 3–5) | Length of followup: 1m
| Entered into study: 27 | % Male: 78 | Concomitant medications: Cyclosporine | Assay used: HPLC
| Analyzed: 27 | Weight: NR | Prednisone
Author: Reggiani | Aim: To evaluate Tac and MMF with steroids and to evaluate PK of MPA | Population: Liver transplant tx | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: leucopenia, low platelet count, GI and neurological symptoms
Year: 2005 | Comparison of monitored patients with others: No | Organ transplanted: Liver | Dose: 750 mg BID 1st month, 500 mg BID > 1 month | Method of measurement: AUC_0–12_ | Length of followup: mean 31 +/- 7m
Country: Italy | Study design: RCT | Age: Mean for entire population group A: 49.7 +/- 4.6, group B: 50.4 +/- 8.9 | Prospective dose adjustment planned: No | Frequency of MPA measure: 1wk and 1m
| Entered into study: 30 | % Male: Entire population 70, group A: 66.7, group B: 72.2 | Concomitant medications: Tacrolimus group A and B | Assay used: NR
| Group A: 12 patients | Weight: NR | Methylpred. group B
| Group B: 18 patients | | Prednisone group B
| Analyzed: 30
Author: Ringe | Aim: Pilot study to investigate a novel steroid-free immunosuppressive regimen after clinical liver transplantation | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2001 | Comparison of monitored patients with others: No | Organ transplanted: LIver | Dose: 2315 to 2320 mg/kg/day | Method of measurement: 12 hr post dose | diarrhea
Country: Germany | Study design: Case series | Age: Median 51.9y | Prospective dose adjustment planned: No | Frequency of MPA measure: Daily | Length of followup: 2y
| Entered into study: 30 | Range 15–66y | Concomitant medications: Tacrolimus | Assay used: HPLC
| Analyzed: 30 | % Male: 70
| | Weight: NR
Author: Satoh | Aim: To investigate MPA chronopharmacokinetics and relation between MPA circadian exposure and incidence of acute rejection | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2006 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 2 g/day | Method of measurement: C_0_ C_max_ AUC_0–12_ | diarrhea
Country: Japan | Study design: Case series | Age: Mean 41.2 +/- 2.1y | Prospective dose adjustment planned: Yes - based on clinical indicators GI symptoms | Frequency of MPA measure: 13 samples in 24 hrs, just prior, 1, 2, 3, 6, 9, and 12 hr after each dose (2 doses a day) | nausea
| Entered into study: 30 | Range 21–66y | Concomitant medications: Tacrolimus | Assay used: HPLC | abdominal pain
| Analyzed: 30 | % Male: 50 | Methylpred. | | vomiting
| | Weight: Mean 56.4 +/-1.9 | Corticosteroids | | Length of followup: NR
| | Range (37.0–81.0)
Author: Satoh | Aim: To investigate the influence of MMF on incidence of acute rejection and infectious complications | Population: NR | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: viral infection
Year: 2005 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1.0 – 2 g/day | Method of measurement: AUC_(0–12h)_ | acute rejection
Country: Japan | Study design: Prospective Cohort | Age: Mean for entire population AZA: 37.9 +/- 11.5 MMF: 44.3 +/- 11.6 | Prospective dose adjustment planned: Yes - based on clinical indicators | Frequency of MPA measure: just before dose and 1, 2, 3, 6, 9 and 12 h after morning oral administration | CMV infections
| Entered into study: 66 | % Male: Entire population AZA: 54.5, MMF: 59.1 | Concomitant medications: Tacrolimus | Assay used: HPLC | Varicella
| Analyzed: 66 | Weight: NR | Methylpred. | | Zoster
| | | Prednisone | | Malignancy related Epstein-Barr
| | | | | Adenovirus hemorrhagic cystitis
| | | | | Length of followup: 28d
Author: Shaw | Aim: Possibility of an effect of ethnicity on the PK of MPA | Population: Adult renal transplant | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: Rejection, leukopenia, gastrointestinal toxicity
Year: 2000 | Comparison of monitored patients with others: Yes Two set s of monitored patients: | Organ transplanted: Kidney (Renal) | Dose: 1g BID | MPAG | Length of followup: 90d
Country: USA | AUC controlled vs MPA C_0_ | Age: Range 47 +/-9.7y | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels AUC level, predose trough level | Method of measurement: C_0_ C_max_ AUC_0–12_(as predicted by LSS of C_0_, C_20_, C_40_, C_75_, C_120_)
| Study design: Prospective Cohort | % Male: 70 | Concomitant medications: Neoral Steriods | Frequency of MPA measure: day 4, 7, 14, 28, 90
| Entered into study: African American: 13 | Weight: NR | | Assay used: HPLC
| Caucasian: 20
| Analyzed: NR
Author: Shaw | Aim: PK of MPA in Renal Transplant patients with delayed graft function | Population: recent kidney transplant with delayed graft function having one hemodialysis within previous 24 hr. | Form given: Mycophenolate mofetil (MMF, CellCept) oral MMF | Form measured: MPA | Health outcome: hemodialysis did not lower MPA plasma concentration hemodialysis id remove some MPAG from the blood renal function is the primary determinant of MPAG plasma concentration
Year: 1997 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 3 g/day for 28d | MPAG | Length of followup:
Country: USA | Study design: Case series | Age: Range 31–58y | Prospective dose adjustment planned: No | fMPA MPA free faction | 28d
| Entered into study: 8 | % Male: 50% | Concomitant medications: Cyclosporine | Method of measurement: Predose concentration
| Analyzed: 8 | Weight: NR | Methylpred. | MPA free faction %creatinine linear regression model
| | | azathioprine | Frequency of MPA measure: predose plus 7 X/d once a wk for 5 wks
| | | | Assay used: HPLC
Author: Smak Gregoor | Aim: Compare the effect of conversion to either MMF or AZA with predisone | Population: Stable kidney recipients on CsA and prednisone 1 year post transplant | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection side effects
Year: 2000b | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1g BID | Method of measurement: C_0_, C_12h_ | Length of followup: MMF: 1.61 +/- 0.6y
Country: Netherlands | Study design: RCT | Age: Mean for entire population MMF - 46; AZA - 44 | Prospective dose adjustment planned: No prescribed plan; only if physician allows | Frequency of MPA measure: NR | AZA: 1.72 +/- 0.54y
| Entered into study: Condition 1 MMF - 34 | Range for entire population MMF - 21–73; AZA - 22–67 | Concomitant medications: Prednisone | Assay used: EMIT
| Condition 2 AZA - 30 | % Male: Entire population MMF - 56, AZA - 60
| Analyzed: 64 | Weight: NR
Author: Smak Gregoor | Aim: Describes the results of dose reduction and MPA trough levels in renal tranplant patients treated with MMF and prednisone | Population: Stable 1y post kidney tx | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: rejection
Year: 2000a | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1 g BID, 750 mg BID, 500 mg BID | Method of measurement: Trough levels | Length of followup: 1y
Country: Netherlands | Study design: Case series | Age: NR | Prospective dose adjustment planned: No | Frequency of MPA measure: 4,8,12m
| Entered into study: 27 | % Male: NR | Concomitant medications: Prednisone | Assay used: EMIT
| Analyzed: 27 | Weight: NR
Author: Smak Gregoor | Aim: The results of monitoring MPA trough levels in relation to adverse events. | Population: patients converted from azathioprine cyclosporin and prednisone to MMF, cyclosporin & prednisone 1y after transplant | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: hair loss (alopecia)
Year: 1998 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 2 g/day | Method of measurement: MPA trough levels | anemia
Country: Netherlands | Study design: Case series | Age: NR | Prospective dose adjustment planned: No | Frequency of MPA measure: 3 times over 2 wks | Length of followup: 2w
| Entered into study: 24 | % Male: NR | Concomitant medications: Cyclosporine | Assay used: EMIT
| Analyzed: 15 | Weight: NR | Prednisone
Author: Sugioka | Aim: To obtain more useful information for therapeutic drug monitoring of MPA after MMF dosing in Japanese renal transplant patients | Population: Recent renal tx patients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: leukopenia diarrhea
Year: 2006 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: MPA group: 1000 to 1500 mg/day | Method of measurement: AUC_(0–9h)_ | Length of followup: 28d
Country: Japan | Study design: Case series | Age: Range for entire population MPA group: 7–69y, PSL group: 11 – 66y | Prospective dose adjustment planned: No | Frequency of MPA measure: day 7, 14, 21, 28 post transplantation
| Entered into study: Entire population 83 | % Male: Entire population MPA group: 65.1 PSL group: 55 both: 62.7 | Concomitant medications: Cyclosporine | Assay used: EMIT
| Condition 1 63 | Weight: NR | Tacrolimus
| Condition 2 20
| Analyzed: Condition 1 53 on day 14, 50 on day 28
| Condition 2 NR
Author: Sumethkul | Aim: To assess early MPA delivery by E-MPS | Population: NR | Form given: Mycophenolate sodium (Myfortic - enteric coated, EC - delayed release) | Form measured: MPA | Health outcome: GI side effects acute allograft dysfunction borderline acute rejection
Year: 2005 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 720 mg BID | MPAG | Length of followup: 3 – 8m
Country: Thailand | Study design: Case series | Age: Mean 39 +/- 9y | Prospective dose adjustment planned: No | Method of measurement: AUC_(0–12h)_
| Entered into study: 12 | % Male: NR | Concomitant medications: Cyclosporine | Frequency of MPA measure: NR
| Analyzed: 12 | Weight: Mean 48.1 +/- 8.8kg | Prednisone | Assay used: HPLC
Author: Takahashi | Aim: MMF in the prevention of acute rejection following renal transplant. | Population: Patients receiving first renal transplant, ≥16y | Form given: Mycophenolate mofetil (MMF, CellCept) MMF (RS-61443) | Form measured: MPA | Health outcome: patient survival
Year: 1995 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1000, 2000, or 3000 mg/day | Method of measurement: C_0_ AUC_0–12_ | graft survival
Country: Japan | Study design: Non-randomized Controlled Trial | Age: Range: 37.7–41y | Prospective dose adjustment planned: No | Frequency of MPA measure: Trough plasma levels and 12-hour AUC were monitored at weeks 1, 2 & 3. Clicial lab testing including CMV titers was performed on a weekly or biweekly basis. | pancytopenia gastrointestinal disturbances
| Entered into study: Condition 1 1000 mg n=12 | % Male: 68.75% | Concomitant medications: Cyclosporine steroids (no description) | Assay used: NR | numbness of limbs & tongue hemorrhagic duodenal ulcer
| Condition 2 2000 mg n= 10 | Weight: NR | | | Length of followup: 12wks
| Condition 3 3000 mg n=10
| Analyzed: Condition 1 1000 mg n = 12
| Condition 2 2000 mg n= 9
| Condition 3 3000 mg n= 10
Author: Tredger | Aim: To determine a target range of MPA plasma levels that reduced adverse events | Population: Liver allograft recipients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2004 | Comparison of monitored patients with others: No | Organ transplanted: Liver | Dose: adults: 500 mg BID then increased, children: 5 mg/kg BID then increased | Method of measurement: trough levels | leucopenia infection
Country: UK | Study design: Prospective Cohort | Age: Mean for entire population adults median: 50.1y, children median: 3.5y | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels to achieve therapeuic levels and also based on clinical | Frequency of MPA measure: 3 assays per week | GI
| Entered into study: 147 adults, 63 children | Range for entire population adults: 16.9 – 71.8y, children: 0.3 – 19.5y | Concomitant medications: Cyclosporine | Assay used: EMIT | Length of followup: 2y
| Analyzed: 147 adults, 63 children | % Male: Entire population adults: 53.1, children: 49.2 | Tacrolimus
| | Weight: NR
Author: Tsaroucha | Aim: Determine the therapeutic trough levels of MPA and MPAG in kidney, liver and small bowel transplant patients who received both Tac and MMF, in order to assess potential differences in the bioavailability. i.e., effectiveness of this agent between the three groups | Population: liver, small bowel and kidney tx | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: rejection
Year: 2000 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: liver: 0.0258 g/kg/day | MPAG | Length of followup: liver: 165d;
Country: USA | Study design: Prospective Cohort | Liver | small bowel: 0.0822 g/kg/day | Method of measurement: trough | small bowel: 58d;
| Entered into study: Condition 1 liver: 83 | Small bowel | kidney: 0.0194 g/kg/day | Frequency of MPA measure: 5 to 30 measures/subject | kidney: 373d; all post transplant
| Condition 2 small bowel: 15 | Age: Mean for groups: liver: 41.4 +/- 4.6y; small bowel: 18.7 +/- 3.9y; kidney: 44.3 +/- 2.7y | Prospective dose adjustment planned: No | Assay used: HPLC
| Condition 3 kidney: 25 | % Male: liver: 70; small bowel: 40; kidney: 52 | Concomitant medications: Tacrolimus
| Analyzed: Condition 1 liver: 83 | Weight: Mean liver: 74.2; small bowel: 38.7; kidney: 77.1 | steroids
| Condition 2 small bowel: 15
| Condition 3 kidney: 25
Author: van Besouw | Aim: Observe the effect of MMF on haematological parameters such as haemoglobin (Hb), leukocytes and thrombocytes | Population: Stable renal tx patients without rejection at 12m post tx | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: leukocytes decrease in Hb
Year: 1999 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 2 g/day - 1 g/day | Method of measurement: trough | Length of followup: 8m
Country: Netherlands | Study design: Case series | Age: NR | Prospective dose adjustment planned: No | Frequency of MPA measure: 4m to 8m on MPA 16m to 20m post tx
| Entered into study: 26 | % Male: 46 | Concomitant medications: Prednisone | Assay used: EMIT
| Analyzed: 26 | Weight: NR
Author: van Gelder | Aim: Provide a data set consisting of well-distributed MPA area under the curve (AUC) data in a population of kidney transplant recipients, using biopsy-proven rejection over a 6-month period after transplantation as the end point | Population: Adult recipients of a primary or secondary cadaveric kidney transplant; | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection adverse events (vomit, abdominal pain, diarrhea leukopenia pneumonia
Year: 1999 | Comparison of monitored patients with others: Three target MPA AUC values compared | Caucasian L: 94.1%, I: 91.5%, H: 94.2% | Dose: L: 16.1 ug hr/ml | Method of measurement: C_0_ C_max_ AUC_0–12_ | Length of followup: 6m
Country: Netherlands | Study design: RCT | Organ transplanted: Kidney (Renal) | I: 32.2 ug hr/ml | Frequency of MPA measure: day 3, 7, 11, 21, 28 week 8, 12, 16, 20
| Entered into study: 154 | Age: Range L: 47.8 +/- 11.5; I: 46.9 +/- 13.8; H: 50.6 +/- 10.5 | H: 60.6 ug hr/ml | Assay used: HPLC
| Analyzed: 150 | % Male: L: 58.8; I: 63.8; H: 59.6 | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels
| | Weight: Range | Concomitant medications: Cyclosporine
| | L: 69.8 +/- 12.5 kg | Prednisone
| | I: 65.9 +/- 13.1 kg | Corticosteroids
| | H: 67.4 +/- 11.3 kg
Author: Wang | Aim: Compare the efficiency and safety of MMF on the dosage between 2.0 g/day and 1.5 g/day in order to find appropriate doasge of MMF | Population: Primary cadaveric renal tx recipients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: Mild rejection, adverse effects
Year: 1998 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: Group 1. 1.0 g BID | Method of measurement: C_0_ C_max_ AUC_0–12_ | Length of followup: 3m
Country: China | Study design: RCT | Age: Range 35–59y | Group 2. 0.75 g BID | Frequency of MPA measure: day 21
| Entered into study: 13 | % Male: 54 | Prospective dose adjustment planned: Yes - based on clinical indicators | Assay used: HPLC
| Analyzed: 13 | Weight: Range 35–68 kg | Concomitant medications: Cyclosporine
| | | Corticosteroids
| | | Methylpred.
| | | Prednisone
Author: Wang | Aim: Explore the PK characteristics and therapeutic window of MPA in elderly Chinese recipients to establish a practical model equation to estimate MPA AUC in this age group by LSS | Population: Chinese patients, elderly group versus adult group | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: Acute rejection
Year: 2007 | Comparison of monitored patients with others: No | Organ transplanted: Kidney | Dose: First 2–4w: 0.75 g BID | Method of measurement: C_0_, AUC_0–12_ | Severe adverse events: pneumonia, leukocytepenia, death
Country: China | Study design: Prospective cohort | Age: Elderly group: 65.6 ± 3.6y | After 2–4w, 0.5 g BID | Frequency of MPA measure: Once at 10–12w | Length of followup: 6m
| Entered into study: Elderly group: 24 | Adult group: 39.6 ± 14.3y | Prospective dose adjustment planned: No | Assay used: HPLC
| Adult group: 24 | % Male: Elderly group:: 71 | Concomitant medications: Cyclosporine
| Analyzed: Elderly group: 24 | Adult group: 63 | Prednisone
| Adult group: 24 | Weight: Elderly group: 61.4 ± 8.6kg
| | Adult group: 65.9 ± 10.8kg
Author: Weber | Aim: To estimate MPA exposure in pediatric renal transplant patients | Population: German study: 54 pediatric renal transplant patients in the German study group on MMF therapy; 44 had primary transplant function, 10 had delayed graft function suspension trial: 25 pediatric renal transplant recipients in the Tricontinental MMF trial | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA German study and suspension trial | Health outcome: acute rejection side effects such as leukopenia and infections
Year: 2006 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: German study: 600 mg/m2 BSA up to 2 g/day suspension trial: 600 mg/m2 body surface area BID (up to 1000mg BID), corresponding to 1 g MMF BID in adult renal transplant recipients | MPAG suspension trial | Length of followup: German study: 6m post transplant suspension trial: 36m
Country: Germany | Study design: Case series | Age: Inclusion requirement NR (published in previous reports) | Prospective dose adjustment planned: No | Method of measurement: suspension trial
| Entered into study: Condition 1: 54 | Range for entire population german study: 3.17–16.0y, suspension trial: 1.0–16.0y | Concomitant medications: Cyclosporine CsA microemulsion: | Frequency of MPA measure: german study: day 7 and 21 post transplant (initial phase) and 3 and 6m post transplant (stable phase) suspension trial: day 7 and month 3, 9, 24, and 36
| Condition 2: 25 | % Male: Entire population German study: 61.1, suspension trial: 68.0, both: 63.3 | German study and suspension trial Methylpred. German study | Assay used: HPLC German study
| Analyzed: Condition 1: 54 | Weight: NR | Prednisone suspension trial corticosteroids | EMIT German study
| Condition 2: 25 | | | LC-MS suspension trial
Author: Weber | Aim: To determine the utility of the EMIT assay compared to the HPLC in identifying pediatric renal transplant patients at risk for acute graft rejection. | Population: all Caucasian | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2002 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m2 BID to a maximum of 2 g/day | Method of measurement: C_0_ C_max_ AUC_0–12_ AUC_0–2_ | leukopenia
Country: Germany | Study design: Case series | Age: Mean 11.8y | Prospective dose adjustment planned: Yes - based on clinical indicators | Frequency of MPA measure: on day 7 and 21 post transplant (‘initial phase’) and 3 and 6 months post transplant (‘stable phase’) | diarrhea
| Entered into study: 50 | Range 3.2 – 16.0y | Concomitant medications: Cyclosporine | Assay used: HPLC | anemia
| Analyzed: 50 | % Male: 62 | Methylpred. | | Length of followup: 6m
| | Weight: NR | | EMIT
Author: Weber | Aim: To determine the PK-pharmodynamic realtionship for MPA in pediatric renal transplant patients. | Population: All patients were caucasian. | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: acute rejection
Year: 2001 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m2 BSA twice a day up to 2 g/day max | Method of measurement: Predose concentration 0 – 2 hour | leukopenia infections
Country: Germany | Study design: Case series | Age: Inclusion requirement described in study refid 13563, 13860 | Prospective dose adjustment planned: Yes - based on clinical indicators | Predose concentration time to maximum concentration | Length of followup: 6m
| Entered into study: 54 | Range 2.2 – 17.8y | Concomitant medications: Cyclosporine | Frequency of MPA measure: 7 and 21 days post transplant (initial phase), 3 and 6 months post transplant (stable phase)
| Analyzed: 54 | % Male: 61.1 | Methylpred. | Assay used: Not reported described in other studies refid 13860, 13867
| | Weight: NR
Author: Weber | Aim: A sequential investigation of MPA PK in initial and stable phase in pediatric renal transplantat recipients. | Population: pediatric renal transplant patients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: GFR
Year: 1999 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 600 mg/m2 BSA BID to max of 2g/day | MPAG | Length of followup: 6m
Country: Germany | Study design: Case series | Age: Mean 12.0 +/- 0.8y | Prospective dose adjustment planned: No | fMPA
| Entered into study: 17 | Range 5.9–15.8y | Concomitant medications: Cyclosporine | Method of measurement: AUC_(0–12h)_ T_max_ C_max_ C_min_
| Analyzed: 17 | % Male: 53 | Methylpred. | Frequency of MPA measure: day 7, 21 = initial phase, 3, 6 months = stable phase
| | Weight: Mean 37.6 +/- 3.3 | | Assay used: HPLC
Author: Weber | Aim: Evaluation of the PK of MPA in Renal transplant patients. | Population: patients receiving first or second renal transplant | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: transplant dysfunction decreased albumin levels
Year: 1998 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: Children: 600 mg/m2 body surface area BID Adults: 1 g BID | MPAG free MPA | GFR in children creatinine clearance rate in adults
Country: Germany | Study design: Case control | Age: Mean children 10.7 +/- 0.72; adults 45.9 +/- 4.1 | Prospective dose adjustment planned: No | Method of measurement: mimimum concentration | Length of followup: 3w
| Entered into study: Condition 1 children n=18 | Range for entire population children 5.9 – 15.3; adults 20.1 – 59.2 | Concomitant medications: Cyclosporine cyclosporin A | MPA-AUC_(0–12h)_
| Condition 2 adults n=10 | % Male: 64% (adults and children) | Methylpred. | Frequency of MPA measure: day 7 and day 21
| Analyzed: Condition 1 children n=18 | Weight: Mean children: weight 29.3 +/- 2.49 kg; BSA 1.02 +/- 0.06 m (squared). adults: weight 78.7 +/- 3.2 kg; BSA 1.93 +/- 0.04 m (squared) | | Assay used: HPLC reverse phase
| Condition 2 adults n=10 | Range: Children 16–50.3; adults 65.8–98.4
Author: Wolfe | Aim: PK of MMF and IV Ganciclovir alone and in combination in Renal transplant recipients | Population: recent kidney transplant with stable renal functions | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: potential drug interaction between MPA and ganciclovir creatinine clearance
Year: 1995 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: single dose of 1500 mg in each of two treatment arms; one arm alone and one arm combined with ganciclovir | MPAG | Length of followup: 3w
Country: USA | Study design: RCT | Age: Mean 36 +/- 13y | Prospective dose adjustment planned: No | Method of measurement: time to peak concentration area under the concentration time curve apparent volume of distributionoral plasma clearancerenal clearance half lifebl
| Entered into study: 12 | Range 20–57y | Concomitant medications: Cyclosporine | Frequency of MPA measure: blood: before and 12 times in 48 h after dosing. Urine: 48 hour monitoring
| Analyzed: 12 | % Male: 100% | Prednisone | Assay used: HPLC-UV
| | Weight: Mean 79 +/- 19; lean body weight 69.0 +/- 7.5 | Ganciclovir in 2 arms, one arm alone and 1 arm combined with MMF
| | Range 56.9–79.9 | Azathioprine
Author: Wollenberg | Aim: to determine PK data of MPA during different periods after transplant. | Population: enrolled after renal transplantation | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: creatinine
Year: 1998 | Comparison of monitored patients with others: No | Organ transplanted: Kidney (Renal) | Dose: 1 g BID | Method of measurement: trough | Length of followup: >3m
Country: Germany | Study design: Non-randomized Controlled Trial | Age: Mean 48 +/- 15y | Prospective dose adjustment planned: No | Frequency of MPA measure: after MMF dose: 0.5, 1, 2, 4, 6, 8 and 12 h
| Entered into study: Condition 1 24 | % Male: 81 | Concomitant medications: Cyclosporine | Assay used: EMIT
| Condition 2 24 | Weight: Mean BMI 24.4 +/- 2.4 | Prednisone
| Analyzed: Condition 1 24
| Condition 2 24
Author: Yamani | Aim: Evaluate the incidence of rejection in relation to MMF trough level following heart transplantation | Population: Heart tx patients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: rejection VS trough rejection VS CSA/Tac levels VS MPA levels
Year: 2000 | Comparison of monitored patients with others: No | Organ transplanted: Heart (Cardiac) | Dose: 2 g/day | Method of measurement: trough | WBC - lymphocyte (total percent)
Country: USA | Study design: Retrospective Cohort | Age: Range 36 +/- 14y | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels | Frequency of MPA measure: 12m | Length of followup: 179 +/- 52d
| Entered into study: 215 | % Male: 81 | Concomitant medications: Cyclosporine | Assay used: EMIT
| Analyzed: 215 | Weight: NR | Tacrolimus
| | | Prednisone
Author: Zakliczynski | Aim: To assess clinical utility of MPA trough concentration monitoring in heart transplant patients | Population: Post heart tx patients | Form given: Mycophenolate mofetil (MMF, CellCept) | Form measured: MPA | Health outcome: GI symptoms
Year: 2005 | Comparison of monitored patients with others: No | Organ transplanted: Heart (Cardiac) | Dose: 1g BID, 1.5 g BID for adjusted >90kg | Method of measurement: trough levels | leucopenia
Country: Poland | Study design: Case series | Age: Mean 41.9 +/- 16y | Prospective dose adjustment planned: Yes - based on MPA (or metabolite) blood levels | Frequency of MPA measure: NR | anemia
| Entered into study: 76 | % Male: 75 | Concomitant medications: Cyclosporine | Assay used: EMIT | Length of followup: NR
| Analyzed: 76 | Weight: NR | Tacrolimus
| | | Prednisone
| | | Azathioprine

Abbreviations: AcMPAG=Acyl Glucuronide metabolite of mycophenolic acid; AE=adverse effects; AE/R=adverse effects/rejection; AR=acute rejection; AUC=area-under-the-concentration-time curve; ATG= anti-thymocyte globulin; ATS=anti-thymocyte serum; AZA=azathioprine; BID=twice daily; BSA=body surface area; C_0_=predose trough blood concentration; CC=concentration controlled; CL/F=total body clearance; Cmax=maximum blood or plasma concentration; Cmin=minimum blood or plasma concentration; CMV=cytomegalovirus; CNI=calcineurin inhibitors; CsA=cyclosporin A; d=days; DGF=delayed graft function; Elisa=Enzyme-Linked ImmunoSorbent Assay; E-MPS=enteric-coated mycophenolate sodium; EMIT=enzyme-multiplied immunoassay technique; FD=fixed dose; fMPA=free mycophenolic acid; GFR=glomerular filtration rate; GI=gastrointestinal; H=high; Hb=haemoglobin; HCV=hepatitis C virus; HPLC=high-performance liquid chromatography I=intermediate; IMPDH=Iosine 5′-monophosphate dehydrogenase; IRF=impaired renal function; L=low; LSS=limited sampling strategy; MEIA II= microparticle enzyme immunoassay; Methylpred.=methylprednisolone; MMF=mycophenolate mofetil; m=months; MPA=mycophenolic acid; MPAG=mycophenolic acid glucuronide; LC-MS=liquid chromatography-mass spectrophotometry; NR=not reported; OKT3= muromonab-CD3; PK=pharmacokinetic; PSL=prednisolone; RBC=red blood cells; RCT=randomized controlled trial; ROC=receiver operating characteristic; RR=relative risk; SGOT=serum glutamic oxaloacetic transaminase; SGPT=Serum glutamic pyruvic transaminase; SIR=sirolimus; Tac=tacrolimus; TB=tuberculosis; TDM=therapeutic drug monitoring; Tmax=mean time to maximum concentration; tx=transplant; UV=ultraviolet; WBC=white blood cells; y=years

## Alphabetical List of References in Evidence Table

Armstrong VW, Shipkova M, Schutz E, et al. Monitoring of mycophenolic acid in pediatric renal transplant recipients. Transplant Proc. 2001;33(12):1040-3. [pmid: 11267182].
Atcheson BA, Taylor PJ, Mudge DW, et al. Mycophenolic acid pharmacokinetics and related outcomes early after renal transplant. Br J Clin Pharmacol. 2005;59(3):271-80. [pmid: 15752372]. [pmcid: 1884792].
Barbari A, Stephan A, Masri MA, et al. Mycophenolic acid plasma trough level: correlation with clinical outcome. Exp Clin Transplant. 2005b;3(2):355-60. [pmid: 16417443].
Barbari AG, Masri MA, Stephan AG, et al. Cyclosporine lymphocyte maximum level: a new alternative for cyclosporine monitoring in kidney transplantation. Exp Clin Transplant. 2005a;3(1):293-300. [pmid: 15989673].
Behrend M, Lueck R, Pichlmayr R. Mycophenolic acid and mycophenolic acid glucuronide trough levels after renal transplantation. Transplant Proc. 1997;29(7):2936-8. [pmid: 9365620].
Bilbao I, Castells L, Rojas L, et al. Immunosuppression based on mycophenolate mofetil in stable liver transplanted patients. Int Immunopharmacol. 2006;6(1314):1977-83. [pmid: 17161351].
Borrows R, Chusney G, James A, et al. Determinants of mycophenolic acid levels after renal transplantation. Ther Drug Monit. 2005;27(4):442-50. [pmid: 16044100].
Borrows R, Chusney G, Loucaidou M, et al. Mycophenolic acid 12-h trough level monitoring in renal transplantation: association with acute rejection and toxicity. Am J Transplant. 2006;6(1):121-8. [pmid: 16433766].
Braun F, Canelo R, Schutz E, et al. How to handle mycophenolate mofetil in combination with tacrolimus?. Transplant Proc. 1998;30(8):4094-5. [pmid: 9865309].
Brunet M, Martorell J, Oppenheimer F, et al. Pharmacokinetics and pharmacodynamics of mycophenolic acid in stable renal transplant recipients treated with low doses of mycophenolate mofetil. Transpl Int. 2000;13(Suppl 1):S301-S30. [pmid: 11112019].
Brunet M, Cirera I, Martorell J, et al. Sequential determination of pharmacokinetics and pharmacodynamics of mycophenolic acid in liver transplant patients treated with mycophenolate mofetil. Transplantation. 2006;81(4):541-6. [pmid: 16495801].
Brusa P, Ceruti M, Casullo R, et al. Pharmacokinetic monitoring of mycophenolate mofetil in kidney transplanted patients. Farmaco. 2000;55(4):270-5. [pmid: 10966158].
Bunchman T, Navarro M, Broyer M, et al. The use of mycophenolate mofetil suspension in pediatric renal allograft recipients. Pediatr Nephrol. 2001;16(12):978-84. [pmid: 11793083].
Cantin B, Giannetti N, Parekh H, et al. Mycophenolic acid concentrations in long-term heart transplant patients: relationship with calcineurin antagonists and acute rejection. Clin Transplant. 2002;16(3):196-201. [pmid: 12010143].
Cattaneo D, Gaspari F, Ferrari S, et al. Pharmacokinetics help optimizing mycophenolate mofetil dosing in kidney transplant patients. Clin Transplant. 2001;15(6):402-9. [pmid: 11737117].
Deierhoi MH, Kauffman RS, Hudson SL, et al. Experience with Mycophenolate mofetil (RS61443) in renal transplantation at a single center. Ann Surg. 1993;217(5):476-84. [pmid: 8489310]. [pmcid: 1242825].
DeNofrio D, Loh E, Kao A, et al. Mycophenolic acid concentrations are associated with cardiac allograft rejection. J Heart Lung Transplant. 2000;19(11):1071-6. [pmid: 11077224].
Dipchand AI, Pietra B, McCrindle BW, et al. Mycophenolic acid levels in pediatric heart transplant recipients receiving mycophenolate mofetil. J Heart Lung Transplant. 2001;20(10):1035-43. [pmid: 11595558].
Filler G, Lampe D, Mai I, et al. Dosing of MMF in combination with tacrolimus for steroid-resistant vascular rejection in pediatric renal allografts. Transpl Int. 1998;11(Suppl 1):S82-S8. [pmid: 9664950].
Filler G, Gellermann J, Zimmering M, et al. Effect of adding Mycophenolate mofetil in paediatric renal transplant recipients with chronical cyclosporine nephrotoxicity. Transpl Int. 2000;13(3):201-6. [pmid: 10935703].
Flechner SM, Feng J, Mastroianni B, et al. The effect of 2-gram versus 1-gram concentration controlled mycophenolate mofetil on renal transplant outcomes using sirolimus-based calcineurin inhibitor drug-free immunosuppression. Transplantation. 2005;79(8):926-34. [pmid: 15849545].
Gajarski RJ, Crowley DC, Zamberlan MC, et al. Lack of correlation between MMF dose and MPA level in pediatric and young adult cardiac transplant patients: does the MPA level matter?. Am J Transplant. 2004;4(9):1495-500. [pmid: 15307837].
Gonzalez-Roncero FM, Gentil MA, Brunet M, et al. Pharmacokinetics of mycophenolate mofetil in kidney transplant patients with renal insufficiency. Transplant Proc. 2005;37(9):3749-51. [pmid: 16386526].
Grasser B, Iberer F, Schaffellner S, et al. Trough level-guided mycophenolate mofetil rejection prophylaxis in liver transplantation. Transplant Proc. 2001;33(3):2154-6. [pmid: 11377484].
Hale MD, Nicholls AJ, Bullingham RE, et al. The pharmacokinetic-pharmacodynamic relationship for mycophenolate mofetil in renal transplantation. Clin Pharmacol Ther. 1998;64(6):672-83. [pmid: 9871432].
Hazzan M, Labalette M, Copin MC, et al. Predictive factors of acute rejection after early cyclosporine withdrawal in renal transplant recipients who receive mycophenolate mofetil: results from a prospective, randomized trial. J Am Soc Nephrol. 2005;16(8):2509-16. [pmid: 15987748].
Heller T, van Gelder T, Budde K, et al. Plasma concentrations of mycophenolic acid acyl glucuronide are not associated with diarrhea in renal transplant recipients. Am J Transplant. 2007;7(7):1822-31. [pmid: 17532750].
Hesse CJ, Vantrimpont P, Van Riemsdijk-van Overbeeke IC, et al. The value of routine monitoring of mycophenolic acid plasma levels after clinical heart transplantation. Transplant Proc. 2001;33(3):2163-4. [pmid: 11377487].
Hubner GI, Eismann R, Sziegoleit W. Relationship between mycophenolate mofetil side effects and mycophenolic acid plasma trough levels in renal transplant patients. Arzneim - Forsch. 2000;50(10):936-40. [pmid: 11105237].
Johnson AG, Rigby RJ, Taylor PJ, et al. The kinetics of mycophenolic acid and its glucuronide metabolite in adult kidney transplant recipients. Clin Pharmacol Ther. 1999;66(5):492-500. [pmid: 10579476].
Johnson HJ, Swan SK, Heim-Duthoy KL, et al. The pharmacokinetics of a single oral dose of mycophenolate mofetil in patients with varying degrees of renal function. Clin Pharmacol Ther. 1998;63(5):512-8. [pmid: 9630824].
Kaplan B, Meier-Kriesche HU, Friedman G, et al. The effect of renal insufficiency on mycophenolic acid protein binding. J Clin Pharmacol. 1999;39(7):715-20. [pmid: 10392326].
Kiberd BA, Lawen J, Fraser AD, et al. Early adequate mycophenolic acid exposure is associated with less rejection in kidney transplantation. Am J Transplant. 2004;4(7):1079-83. [pmid: 15196064].
Kreis H, Cisterne JM, Land W, et al. Sirolimus in association with mycophenolate mofetil induction for the prevention of acute graft rejection in renal allograft recipients. Transplantation. 2000;69(7):1252-60. [pmid: 10798738].
Krumme B, Wollenberg K, Kirste G, et al. Drug monitoring of mycophenolic acid in the early period after renal transplantation. Transplant Proc. 1998;30(5):1773-4. [pmid: 9723276].
Kuriata-Kordek M, Boratynska M, Klinger M, et al. The efficacy of mycophenolate mofetil treatment in the prevention of acute renal rejection is related to plasma level of mycophenolic acid. Transplant Proc. 2002;34(7):2985-7. [pmid: 12431678].
Kuypers DR, Vanrenterghem Y, Squifflet JP, et al. Twelve-month evaluation of the clinical pharmacokinetics of total and free mycophenolic acid and its glucuronide metabolites in renal allograft recipients on low dose tacrolimus in combination with mycophenolate mofetil. Ther Drug Monit. 2003b;25(5):609-22. [pmid: 14508385].
Kuypers DR, Claes K, Evenepoel P, et al. Long-term changes in mycophenolic acid exposure in combination with tacrolimus and corticosteroids are dose dependent and not reflected by trough plasma concentration: a prospective study in 100 de novo renal allograft recipients. J Clin Pharmacol. 2003a;43(8):866-80. [pmid: 12953344].
Kuypers DR, Claes K, Evenepoel P, et al. Clinical efficacy and toxicity profile of tacrolimus and mycophenolic acid in relation to combined long-term pharmacokinetics in de novo renal allograft recipients. Clin Pharmacol Ther. 2004;75(5):434-47. [pmid: 15116056].
Le Meur Y, Buchler M, Thierry A, et al. Individualized mycophenolate mofetil dosing based on drug exposure significantly improves patient outcomes after renal transplantation. Am J Transplant. 2007;7(11):2496-503. [pmid: 17908276].
Lu XY, Huang HF, Sheng-Tu JZ, et al. Pharmacokinetics of mycophenolic acid in Chinese kidney transplant patients. J Zhejiang Univ. 2005;Science B(9):885-91.
Lu YP, Lin B, Liang MZ, et al. Correlation of mycophenolic acid pharmacokinetic parameters with side effects in Chinese kidney transplant recipients treated with mycophenolate mofetil. Transplant Proc. 2004;36(7):2079-81. [pmid: 15518752].
Lu YP, Zhu YC, Liang MZ, et al. Therapeutic Drug Monitoring of Mycophenolic Acid Can Be Used as Predictor of Clinical Events for Kidney Transplant Recipients Treated With Mycophenolate Mofetil. Transplant Proc. 2006;38(7):2048-50. [pmid: 16979995].
Maes BD, Dalle I, Geboes K, et al. Erosive enterocolitis in mycophenolate mofetil-treated renal-transplant recipients with persistent afebrile diarrhea. Transplantation. 2003;75(5):665-72. [pmid: 12640307].
Mandla R, Midtvedt K, Line PD, et al. Mycophenolic acid clinical pharmacokinetics influenced by a cyclosporine C2 based immunosuppressive regimen in renal allograft recipients. Transpl Int. 2006;19(1):44-53. [pmid: 16359376].
Meiser BM, Pfeiffer M, Schmidt D, et al. The efficacy of the combination of tacrolimus and mycophenolate mofetil for prevention of acute myocardial rejection is dependent on routine monitoring of mycophenolic acid trough acid levels. Transplant Proc. 1999a;31(12):84-7. [pmid: 10083018].
Meiser BM, Pfeiffer M, Schmidt D, et al. Combination therapy with tacrolimus and mycophenolate mofetil following cardiac transplantation: importance of mycophenolic acid therapeutic drug monitoring. J Heart Lung Transplant. 1999b;18(2):143-9. [pmid: 10194038].
Merkel U, Lindner S, Vollandt R, et al. Trough levels of mycophenolic acid and its glucuronidated metabolite in renal transplant recipients. Int J Clin Pharmacol Ther. 2005;43(8):379-88. [pmid: 16119513].
Morgera S, Neumayer HH, Fritsche L, et al. Pharmacokinetics of mycophenolate mofetil in renal transplant recipients on peritoneal dialysis. Int J Clin Pharmacol Ther. 1998b;36(3):159-63. [pmid: 9562232].
Morgera S, Budde K, Lampe D, et al. Mycophenolate mofetil pharmacokinetics in renal transplant recipients on peritoneal dialysis. Transpl Int. 1998a;11(1):53-7. [pmid: 9503555].
Mourad M, Chaib-Eddour D, Malaise J, et al. Analytical and clinical evaluation of the EMIT mycophenolic acid immunoassay in kidney transplantation. Transplant Proc. 2000;32(2):404-6. [pmid: 10715456].
Mourad M, Malaise J, Chaib ED, et al. Pharmacokinetic basis for the efficient and safe use of low-dose mycophenolate mofetil in combination with tacrolimus in kidney transplantation. Clin Chem. 2001b;47(7):1241-8. [pmid: 11427455].
Mourad M, Malaise J, Chaib ED, et al. Correlation of mycophenolic acid pharmacokinetic parameters with side effects in kidney transplant patients treated with mycophenolate mofetil. Clin Chem. 2001a;47(1):88-94. [pmid: 11148182].
Mudge DW, Atcheson B, Taylor PJ, et al. The effect of oral iron admiinistration on mycophenolate mofetil absorption in renal transplant recipients: a randomized, controlled trial. Transplantation. 2004;77(2):206-9. [pmid: 14742982].
Naesens M, Kuypers DRJ, Verbeke K, et al. Multidrug resistance protein 2 genetic polymorphisms influence mycophenolic acid exposure in renal allograft recipients. Transplantation. 2006;82(8):1074-84. [pmid: 17060857].
Naito T, Shinno K, Maeda T, et al. Effects of calcineurin inhibitors on pharmacokinetics of mycophenolic acid and its glucuronide metabolite during the maintenance period following renal transplantation. Biol Pharm Bull. 2006;29(2):275-80. [pmid: 16462031].
Okamoto M, Wakabayashi Y, Higuchi A, et al. Therapeutic drug monitoring of mycophenolic acid in renal transplant recipients. Transplant Proc. 2005;37(2):859-60. [pmid: 15848556].
Orlando G, Baiocchi L, Cardillo A, et al. Switch to 1.5 grams MMF monotherapy for CNI-related toxicity in liver transplantation is safe and improves renal function, dyslipidemia, and hypertension. Liver Transpl. 2007;13(1):46-54. [pmid: 17154392].
Pape L, Ehrich JH, Offner G. Long-term follow-up of pediatric transplant recipients: mycophenolic acid trough levels are not a good indicator for long-term graft function. Clin Transplant. 2004;18(5):576-9. [pmid: 15344963].
Pawinski T, Durlik M, Szlaska I, et al. Comparison of mycophenolic acid pharmacokinetic parameters in kidney transplant patients within the first 3 months post-transplant. J Clin Pharm Ther. 2006b;31(1):27-34. [pmid: 16476117].
Pawinski T, Durlik M, Szlaska I, et al. The weight of pharmacokinetic parameters for mycophenolic acid in prediction of rejection outcome: the receiver operating characteristic curve analysis. Transplant Proc. 2006a;38(1):86-9. [pmid: 16504671].
Pillans PI, Rigby RJ, Kubler P, et al. A retrospective analysis of mycophenolic acid and cyclosporin concentrations with acute rejection in renal transplant recipients. Clin Biochem. 2001;34(1):77-81. [pmid: 11239520].
Reggiani P, Arru M, Regazzi M, et al. A “steroid-free” tacrolimus and low-dose mycophenolate mofetil primary immunosuppression does not prevent early acute rejection after liver transplantation. Transplant Proc. 2005;37(4):1697-9. [pmid: 15919435].
Ringe B, Braun F, Schutz E, et al. A novel management strategy of steroid-free immunosuppression after liver transplantation: efficacy and safety of tacrolimus and mycophenolate mofetil. Transplantation. 2001;71(4):508-15. [pmid: 11258429].
Satoh S, Tada H, Murakami M, et al. The influence of mycophenolate mofetil versus azathioprine and mycophenolic acid pharmacokinetics on the incidence of acute rejection and infectious complications after renal transplantation. Transplant Proc. 2005;37(4):1751-3. [pmid: 15919454].
Satoh S, Tada H, Murakami M, et al. Circadian pharmacokinetics of mycophenolic Acid and implication of genetic polymorphisms for early clinical events in renal transplant recipients. Transplantation. 2006;82(4):486-93. [pmid: 16926592].
Shaw LM, Mick R, Nowak I, et al. Pharmacokinetics of mycophenolic acid in renal transplant patients with delayed graft function. J Clin Pharmacol. 1998;38(3):268-75. [pmid: 9549665].
Shaw LM, Korecka M, Aradhye S, et al. Mycophenolic acid area under the curve values in African American and Caucasian renal transplant patients are comparable. J Clin Pharmacol. 2000;40(6):624-33. [pmid: 10868313].
Smak Gregoor PJ, Hesse CJ, van Gelder T, et al. Relation of mycophenolic acid trough levels and adverse events in kidney allograft recipients. Transplant Proc. 1998;30(4):1192-3. [pmid: 9636482].
Smak Gregoor PJ, van Gelder T, van Besouw NM, et al. Randomized study on the conversion of treatment with cyclosporine to azathioprine or mycophenolate mofetil followed by dose reduction. Transplantation. 2000b;70(1):143-8. [pmid: 10919591].
Smak Gregoor PJ, van Gelder T, van Besouw NM, et al. Mycophenolic acid trough levels after kidney transplantation in a cyclosporine-free protocol. Transpl Int. 2000a;13(Suppl 1):S333-S33. [pmid: 11112026].
Sugioka N, Sasaki T, Kokuhu T, et al. Clinical pharmacokinetics of mycophenolate mofetil in Japanese renal transplant recipients: A retrospective cohort study in a single center. Biol Pharm Bull. 2006;29(10):2099-105. [pmid: 17015958].
Sumethkul V, Na-Bangchang K, Kantachuvesiri S, et al. Standard dose enteric-coated mycophenolate sodium (myfortic) delivers rapid therapeutic mycophenolic acid exposure in kidney transplant recipients. Transplant Proc. 2005;37(2):861-3. [pmid: 15848557].
Takahashi K, Ochiai T, Uchida K, et al. Pilot study of mycophenolate mofetil (RS-61443) in the prevention of acute rejection following renal transplantation in Japanese patients. RS-61443 Investigation Committee—Japan. Transplant Proc. 1995;27(1):1421-4. [pmid: 7878933].
Tredger JM, Brown NW, Adams J, et al. Monitoring mycophenolate in liver transplant recipients: toward a therapeutic range. Liver Transpl. 2004;10(4):492-502. [pmid: 15048791].
Tsaroucha AK, Zucker K, Esquenazi V, et al. Levels of mycophenolic acid and its glucuronide derivative in the plasma of liver, small bowel and kidney transplant patients receiving tacrolimus and cellcept combination therapy. Transpl Immunol. 2000;8(2):143-6. [pmid: 11005321].
van Besouw NM, Van Der Mast BJ, Smak Gregoor PJ, et al. Effect of mycophenolate mofetil on erythropoiesis in stable renal transplant patients is correlated with mycophenolic acid trough levels. Nephrol Dial Transplant. 1999;14(11):2710-3. [pmid: 10534517].
van Gelder T, Hilbrands LB, Vanrenterghem Y, et al. A randomized double-blind, multicenter plasma concentration controlled study of the safety and efficacy of oral mycophenolate mofetil for the prevention of acute rejection after kidney transplantation. Transplantation. 1999;68(2):261-6. [pmid: 10440399].
Wang CX, Meng FH, Chen LZ, et al. Population Pharmacokinetics of Mycophenolic Acid in Senile Chinese Kidney Transplant Recipients. Transplant Proc. 2007;39(5):1392-5. [pmid: 17580146].
Wang X, Tang X, Xu D. Immunosuppressive effect of mycophenolate mofetil with two different dosages in cadaveric renal transplantation: a short study. Transplant Proc. 1998;30(7):3573-4. [pmid: 9838564].
Weber LT, Shipkova M, Lamersdorf T, et al. Pharmacokinetics of mycophenolic acid (MPA) and determinants of MPA free fraction in pediatric and adult renal transplant recipients. German Study group on Mycophenolate Mofetil Therapy in Pediatric Renal Transplant Recipients. J Am Soc Nephrol. 1998;9(8):1511-20. [pmid: 9697675].
Weber LT, Lamersdorf T, Shipkova M, et al. Area under the plasma concentration-time curve for total, but not for free, mycophenolic acid increases in the stable phase after renal transplantation: a longitudinal study in pediatric patients. German Study Group on Mycophenolate Mofetil Therapy in Pediatric Renal Transplant Recipients. Ther Drug Monit. 1999;21(5):498-506. [pmid: 10519445].
Weber LT, Shipkova M, Armstrong VW, et al. The pharmacokinetic-pharmacodynamic relationship for total and free mycophenolic Acid in pediatric renal transplant recipients: a report of the german study group on mycophenolate mofetil therapy. J Am Soc Nephrol. 2002;13(3):759-68. [pmid: 11856782].
Weber LT, Shipkova M, Armstrong VW, et al. Comparison of the Emit immunoassay with HPLC for therapeutic drug monitoring of mycophenolic acid in pediatric renal-transplant recipients on mycophenolate mofetil therapy. Clin Chem. 2002;48(3):517-25. [pmid: 11861442].
Weber LT, Hoecker B, Armstrong VW, et al. Validation of an abbreviated pharmacokinetic profile for the estimation of mycophenolic acid exposure in pediatric renal transplant recipients. Ther Drug Monit. 2006;28(5):623-31. [pmid: 17038876].
Wolfe EJ, Mathur V, Tomlanovich S, et al. Pharmacokinetics of mycophenolate mofetil and intravenous ganciclovir alone and in combination in renal transplant recipients. Pharmacotherapy. 1997;17(3):591-8. [pmid: 9165564].
Wollenberg K, Krumme B, Schollmeyer P, et al. Pharmacokinetics of mycophenolic acid after renal transplantation. Transplant Proc. 1998;30(5):2237-9. [pmid: 9723455].
Yamani MH, Starling RC, Goormastic M, et al. The impact of routine mycophenolate mofetil drug monitoring on the treatment of cardiac allograft rejection. Transplantation. 2000;69(11):2326-30. [pmid: 10868634].
Zakliczynski M, Szewczyk M, Zakliczynska H, et al. Clinical application of monitoring mycophenolic acid trough concentration in heart transplant recipients—single center's experience. Ann Transplant. 2005;10(2):38-45. [pmid: 16218032].