# Appendix B. Forms/Guides

To see the Forms/Guides, please select the link below. This link will take you to a PDF version of the forms

Forms/Guides