# Appendix A. Exact Search Strings

## Database: Ovid MEDLINE^®^

1 Mycophenolic Acid/
2 mmf.ti,ab.
3 myfortic.mp.
4 cell?ept.mp.
5 mycophenol$.mp.
6 mofetil.mp.
7 mycofenolate.mp.
8 or/1–7
9 exp Kidney Transplantation/
10 exp Heart Transplantation/
11 exp liver transplantation/ or exp pancreas transplantation/
12 exp Lung Transplantation/
13 exp Graft Rejection/
14 exp Organ Transplantation/
15 ((transplant$ or graft) adj4 (kidney or renal or lung$ or cardiac or heart or pancreas or liver or organ or reject$ or patient$)).ti,ab.
16 or/9–15
17 drug monitoring/ or monitoring, immunologic/
18 Dose-Response Relationship, Drug/
19 exp Pharmacokinetics/
20 (monitor$ or sampl$ or measur$).ti,ab.
21 or/17–19,20
22 16 or 21
23 22 and 8
24 (transplant immunology or transplant infectious disease or transplant international or transplantation or transplantation bulletin or transplantation proceedings or transplantation reviews or transplantation science).jn.
25 24 and 8
26 23 or 25
27 exp *Cell Transplantation/
28 26 not 27
29 humans/
30 animals/
31 29 and 30
32 30 not 31
33 28 not 32

## Database: EMBASE^®^

1 Mycophenolic Acid/
2 mmf.ti,ab.
3 myfortic.mp.
4 cell?ept.mp.
5 mycophenol$.mp.
6 mofetil.mp.
7 mycofenolate.mp.
8 exp Mycophenolic Acid 2 Morpholinoethyl Ester/
9 or/1–8
10 exp organ transplantation/
11 exp Graft Rejection/
12 Graft Recipient/
13 ((transplant$ or graft) adj4 (kidney or renal or lung$ or cardiac or heart or pancreas or liver or organ or reject$ or patient$)).ti,ab.
14 or/10–13
15 Dose-Response Relationship, Drug/
16 drug monitoring/ or monitoring, immunologic/
17 exp pharmacokinetics/
18 or/15–17
19 14 or 18
20 19 and 9
21 (transp sci or transplant immunology or transplant international or transplantation or transplantation proceedings or transplantation reviews).jn.
22 21 and 9
23 exp *Stem Cell Transplantation/
24 human.sh.
25 nonhuman.sh.
26 animal.sh.
27 animal experiment.sh.
28 25 or 26 or 27
29 24 and 28
30 (monitoring or sampling or measur$).ti,ab.
31 30 and 9
32 31 or 20
33 32 or 22
34 33 not 23
35 34 not 28
36 34 and 29
37 35 or 36

## Database: EBM Reviews - Cochrane Central Register of Controlled Trials^®^

1 Mycophenolic Acid/
2 mmf.ti,ab.
3 myfortic.mp.
4 cell?ept.mp.
5 mycophenol$.mp.
6 mofetil.mp.
7 mycofenolate.mp.
8 or/1–7
9 exp Kidney Transplantation/
10 exp Heart Transplantation/
11 exp liver transplantation/ or exp pancreas transplantation/
12 exp Lung Transplantation/
13 exp Graft Rejection/
14 exp Organ Transplantation/
15 ((transplant$ or graft) adj4 (kidney or renal or lung$ or cardiac or heart or pancreas or liver or organ or reject$ or patient$)).ti,ab.
16 or/9–15
17 drug monitoring/ or monitoring, immunologic/
18 Dose-Response Relationship, Drug/
19 exp Pharmacokinetics/
20 (monitor$ or sampl$ or measur$).ti,ab.
21 or/17–20
22 16 or 21
23 22 and 8
24 (transplant immunology or transplant infectious disease or transplant international or transplantation or transplantation bulletin or transplantation proceedings or transplantation reviews or transplantation science).jn.
25 24 and 8
26 23 or 25
27 exp *Cell Transplantation/
28 26 not 27

## Database: EBM Reviews - Cochrane Database of Systematic Reviews^®^

1 mmf.ti,ab.
2 myfortic.mp.
3 cell?ept.mp.
4 mycophenol$.mp.
5 mofetil.mp.
6 mycofenol$.mp.
7 or/1–6 (34)
8 ((transplant$ or graft) adj4 (kidney or renal or lung$ or cardiac or heart or pancreas or liver or organ or reject$ or patient$)).ti,ab.
9 (monitor$ or sampl$ or measur$).ti,ab.
10 8 or 9
11 10 and 7

## Database: BIOSIS^®^ Previews

1 TS=(mycophenol*)
2 TS=transplant*
3 #2 AND #1
4 TS=(mycophenol* OR myfortic OR cellcept or mofetil)
5 CH=mycophenolate mofetil
6 #5 OR #4
7 MQ=organ transplantation
8 TS=((liver OR kidney OR renal OR pancrea* OR heart OR cardiac OR lung OR organ OR reject* OR patient) SAME (transplan* OR graft))
9 #8 OR #7
10 10.#9 AND #6